# Acknowledgments

The principal investigator and research team would like to acknowledge the guidance provided by the Technical Expert Panel members (see below), the careful work of the reviewers, and the invaluable assistance of Julie Newell, Jianglai Zhang, Scott Hiromoto, Yuyan (Sabrina) Shi, and Zhen (Frank) Wang.

## Technical Expert Panel

Marc C. Hochberg, M.D., M.P.H., University of Maryland School of Medicine, Baltimore, MD

Lee J. Melton III, M.D., M.P.H., Mayo Clinic, Rochester, MN

Paul D. Miller, M.D., F.A.C.P., Colorado Center for Bone Research, Lakewood, CO

Marcel E. Salive, M.D., M.P.H., Center for Medicare & Medicaid Services, Baltimore, MD

Katherine Sherif, M.D., Drexel University College of Medicine, Philadelphia, PA

## AHRQ Contacts

- Beth A. Collins-Sharp, Ph.D., R.N.
- Director
- Evidence-based Practice Center Program
- Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality
- Rockville, MD

- Gurvaneet Randhawa, M.D., M.P.H.
- Task Order Officer
- Evidence-based Practice Center Program
- Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality
- Rockville, MD