# Appendix E Adverse Events Analyses

| | | | Drug 1 | | Drug 2
Event Category | drug1 | drug2 | # studies | # events | sample size | #events | sample size | OR (95% CI)
Cardiac (mild) | Alendr | placebo | 7 | 61 | 541 | 53 | 429 | 0.96(0.62, 1.47)
Cardiac (mild) | Ibandr | placebo | 4 | 515 | 2613 | 254 | 1189 | 0.98(0.82, 1.17)
Cardiac (mild) | Risedr | placebo | 2 | 0 | 187 | 3 | 85 | 0(0, 1.14)
Cardiac (mild) | Calcit | placebo | 2 | 1 | 166 | 2 | 103 | 0.3(0, 6.06)
Cardiac (mild) | Estrog | placebo | 2 | 25 | 157 | 32 | 157 | 0.73(0.38, 1.37)
Cardiac (mild) | Ralox | placebo | 6 | 86 | 1658 | 39 | 1028 | 1.53(1.01, 2.35)*
Cardiac (mild) | PTH | placebo | 1 | 1 | 8 | 0 | 8 | Inf+(0.03, Inf+)
Cardiac (mild) | Alendr | Calcit | 1 | 3 | 118 | 0 | 123 | Inf+(0.43, Inf+)
Cardiac (mild) | Alendr | Estrog | 1 | 25 | 93 | 23 | 93 | 1.12(0.55, 2.28)
Cardiac (mild) | Alendr | Ralox | 2 | 20 | 799 | 14 | 789 | 1.44(0.68, 3.16)
Cardiac (mild) | Alendr | vitd | 1 | 0 | 60 | 1 | 57 | 0(0, 37.1)
Cardiac (mild) | Calcit | PTH | 2 | 5 | 86 | 0 | 81 | Inf+(1.05, Inf+)*
Cardiac (mild) | Ralox | Estrog | 1 | 21 | 123 | 2 | 64 | 6.34(1.47, 57.6)*
Cardiac (serious) | Alendr | placebo | 7 | 231 | 4626 | 151 | 3999 | 1.2(0.96, 1.49)
Cardiac (serious) | Etidro | placebo | 2 | 2 | 34 | 0 | 38 | Inf+(0.21, Inf+)
Cardiac (serious) | Ibandr | placebo | 2 | 131 | 2062 | 68 | 980 | 0.95(0.69, 1.3)
Cardiac (serious) | Pamidr | placebo | 1 | 0 | 31 | 1 | 30 | 0(0, 37.7)
Cardiac (serious) | Risedr | placebo | 3 | 2 | 90 | 2 | 76 | 0.8(0.06, 11.3)
Cardiac (serious) | Zoledr | placebo | 1 | 221 | 3889 | 171 | 3876 | 1.31(1.06, 1.61)*
Cardiac (serious) | Calcit | placebo | 3 | 2 | 128 | 2 | 124 | 0.98(0.07, 13.7)
Cardiac (serious) | Estrog | placebo | 6 | 358 | 6815 | 393 | 7489 | 0.92(0.79, 1.08)
Cardiac (serious) | Estrog-proges | placebo | 3 | 1213 | 9996 | 1209 | 9987 | 1.04(0.93, 1.15)
Cardiac (serious) | Ralox | placebo | 6 | 320 | 8569 | 129 | 4318 | 1.2(0.97, 1.5)
Cardiac (serious) | Tamox | placebo | 1 | 115 | 6681 | 97 | 6707 | 1.19(0.9, 1.58)
Cardiac (serious) | Alendr | Calcit | 1 | 0 | 140 | 1 | 75 | 0(0, 20.9)
Cardiac (serious) | Alendr | Estrog | 2 | 3 | 123 | 1 | 123 | 3.03(0.24, 161)
Cardiac (serious) | Alendr | Estrog-proges | 1 | 99 | 997 | 15 | 110 | 0.7(0.38, 1.35)
Cardiac (serious) | Etidro | Estrog | 1 | 1 | 17 | 0 | 18 | Inf+(0.03, Inf+)
Cardiac (serious) | Calcit | PTH | 1 | 1 | 57 | 1 | 47 | 0.82(0.01, 65.9)
Cardiac (serious) | Ralox | Estrog | 1 | 2 | 309 | 1 | 158 | 1.02(0.05, 60.7)
Acute Coronary Syndrome | Alendr | placebo | 4 | 4 | 373 | 1 | 254 | 3.59(0.35, 180)
Acute Coronary Syndrome | Etidro | placebo | 2 | 2 | 34 | 0 | 38 | Inf+(0.21, Inf+)
Acute Coronary Syndrome | Ibandr | placebo | 1 | 1 | 150 | 0 | 30 | Inf+(0.01, Inf+)
Acute Coronary Syndrome | Pamidr | placebo | 1 | 0 | 31 | 1 | 30 | 0(0, 37.7)
Acute Coronary Syndrome | Risedr | placebo | 2 | 1 | 55 | 2 | 45 | 0.38(0.01, 7.62)
Acute Coronary Syndrome | Zoledr | placebo | 1 | 77 | 3889 | 78 | 3876 | 0.98(0.71, 1.37)
Acute Coronary Syndrome | Calcit | placebo | 3 | 2 | 128 | 2 | 124 | 0.98(0.07, 13.7)
Acute Coronary Syndrome | Estrog | placebo | 5 | 177 | 6092 | 187 | 6196 | 0.94(0.76, 1.18)
Acute Coronary Syndrome | Estrog-proges | placebo | 2 | 809 | 9886 | 819 | 9485 | 0.96(0.86, 1.09)
Acute Coronary Syndrome | Ralox | placebo | 3 | 180 | 8163 | 70 | 4014 | 1.23(0.92, 1.66)
Acute Coronary Syndrome | Tamox | placebo | 1 | 115 | 6681 | 97 | 6707 | 1.19(0.9, 1.58)
Acute Coronary Syndrome | Alendr | Calcit | 1 | 0 | 140 | 1 | 75 | 0(0, 20.9)
Acute Coronary Syndrome | Alendr | Estrog | 2 | 3 | 123 | 0 | 123 | Inf+(0.41, Inf+)
Acute Coronary Syndrome | Etidro | Estrog | 1 | 1 | 17 | 0 | 18 | Inf+(0.03, Inf+)
Acute Coronary Syndrome | Calcit | PTH | 1 | 0 | 57 | 1 | 47 | 0(0, 32.2)
Acute Coronary Syndrome | Ralox | Estrog | 1 | 2 | 309 | 1 | 158 | 1.02(0.05, 60.7)
Cardiac Death | Alendr | placebo | 2 | 2 | 140 | 0 | 90 | Inf+(0.13, Inf+)
Cardiac Death | Etidro | placebo | 1 | 1 | 17 | 0 | 20 | Inf+(0.03, Inf+)
Cardiac Death | Pamidr | placebo | 1 | 0 | 31 | 1 | 30 | 0(0, 37.7)
Cardiac Death | Risedr | placebo | 1 | 1 | 31 | 0 | 29 | Inf+(0.02, Inf+)
Cardiac Death | Zoledr | placebo | 1 | 39 | 3889 | 33 | 3876 | 1.18(0.72, 1.94)
Cardiac Death | Calcit | placebo | 1 | 0 | 16 | 1 | 15 | 0(0, 36.6)
Cardiac Death | Estrog | placebo | 2 | 114 | 5823 | 125 | 5933 | 0.92(0.71, 1.2)
Cardiac Death | Estrog-proges | placebo | 2 | 136 | 9886 | 113 | 9485 | 1.18(0.91, 1.54)
Cardiac Death | Ralox | placebo | 2 | 29 | 7854 | 11 | 3862 | 1.25(0.6, 2.78)
Cardiac Death | Tamox | placebo | 1 | 44 | 6681 | 35 | 6707 | 1.26(0.79, 2.03)
Atrial fibrillation | Alendr | placebo | 1 | 128 | 3236 | 102 | 3223 | 1.26(0.96, 1.66)
Atrial fibrillation | Risedr | placebo | 1 | 1 | 35 | 0 | 31 | Inf+(0.02, Inf+)
Atrial fibrillation | Zoledr | placebo | 1 | 144 | 3889 | 93 | 3876 | 1.56(1.19, 2.06)*
GI (mild) | Alendr | placebo | 54 | 3893 | 11265 | 3411 | 9525 | 1.05(0.99, 1.13)
GI (mild) | Etidro | placebo | 18 | 880 | 8842 | 1248 | 16814 | 1.33(1.21, 1.46)*
GI (mild) | Ibandr | placebo | 10 | 1793 | 5773 | 803 | 2559 | 1.02(0.92, 1.13)
GI (mild) | Pamidr | placebo | 7 | 125 | 340 | 44 | 253 | 3.14(1.93, 5.21)*
GI (mild) | Risedr | placebo | 22 | 2123 | 9601 | 1334 | 5654 | 1.03(0.95, 1.13)
GI (mild) | Zoledr | placebo | 3 | 35 | 362 | 11 | 125 | 1.34(0.6, 3.21)
GI (mild) | Calcit | placebo | 15 | 92 | 799 | 65 | 620 | 0.96(0.63, 1.48)
GI (mild) | Estrog | placebo | 6 | 78 | 1201 | 70 | 1672 | 1(0.65, 1.52)
GI (mild) | Estrog-proges | placebo | 2 | 84 | 1395 | 62 | 1398 | 1.38(0.97, 1.97)
GI (mild) | Ralox | placebo | 8 | 281 | 7199 | 135 | 3816 | 0.97(0.78, 1.21)
GI (mild) | Tamox | placebo | 1 | 1 | 23 | 1 | 23 | 1(0.01, 82)
GI (mild) | PTH | placebo | 2 | 133 | 1383 | 49 | 691 | 1.39(0.98, 2)
GI (mild) | calcium | placebo | 2 | 12 | 237 | 15 | 243 | 0.79(0.33, 1.87)
GI (mild) | vitd | placebo | 3 | 3 | 141 | 10 | 141 | 0.27(0.04, 1.11)
GI (mild) | Alendr | Etidro | 3 | 18 | 132 | 3 | 105 | 5.89(1.61, 32.7)*
GI (mild) | Alendr | Pamidr | 1 | 2 | 21 | 0 | 19 | Inf+(0.17, Inf+)
GI (mild) | Alendr | Risedr | 4 | 340 | 2013 | 249 | 1692 | 1.06(0.88, 1.28)
GI (mild) | Risedr | Zoledr | 1 | 3 | 15 | 0 | 15 | Inf+(0.43, Inf+)
GI (mild) | Alendr | Calcit | 4 | 56 | 413 | 13 | 288 | 3.42(1.79, 7)*
GI (mild) | Alendr | Estrog | 4 | 78 | 255 | 68 | 306 | 1.57(1, 2.46)
GI (mild) | Alendr | Ralox | 5 | 252 | 1301 | 198 | 1296 | 1.33(1.08, 1.64)*
GI (mild) | Alendr | vitd | 10 | 164 | 766 | 136 | 701 | 1.21(0.91, 1.6)
GI (mild) | Etidro | Calcit | 1 | 1 | 66 | 0 | 66 | Inf+(0.03, Inf+)
GI (mild) | Etidro | Estrog | 3 | 10 | 97 | 0 | 99 | Inf+(2.85, Inf+)*
GI (mild) | Etidro | calcium | 7 | 58 | 251 | 50 | 271 | 1.57(0.96, 2.59)
GI (mild) | Etidro | vitd | 2 | 1 | 102 | 1 | 100 | 0.97(0.01, 76.3)
GI (mild) | Ibandr | vitd | 2 | 31 | 110 | 35 | 109 | 0.83(0.44, 1.54)
GI (mild) | Risder | Estrog-proges | 1 | 3 | 15 | 0 | 15 | Inf+(0.43, Inf+)
GI (mild) | Calcit | PTH | 2 | 23 | 86 | 10 | 81 | 2.48(1.04, 6.33)*
GI (mild) | Ralox | Estrog | 2 | 16 | 804 | 16 | 671 | 0.89(0.41, 1.93)
GI (mild) | Ralox | Estrog-proges | 1 | 10 | 495 | 22 | 513 | 0.46(0.19, 1.03)
GI (mild) | calcium | vitd | 1 | 1 | 29 | 6 | 34 | 0.17(0, 1.55)
Upper GI | Alendr | placebo | 46 | 3111 | 12177 | 2602 | 9908 | 1.04(0.97, 1.11)
Upper GI | Etidro | placebo | 15 | 198 | 8668 | 214 | 16633 | 1.53(1.25, 1.88)*
Upper GI | Ibandr | placebo | 5 | 754 | 4624 | 331 | 2204 | 1.06(0.91, 1.24)
Upper GI | Pamidr | placebo | 5 | 89 | 262 | 18 | 183 | 4.31(2.4, 8.06)*
Upper GI | Risedr | placebo | 20 | 1293 | 9474 | 833 | 5568 | 1.07(0.96, 1.19)
Upper GI | Zoledr | placebo | 2 | 26 | 307 | 3 | 74 | 1.82(0.53, 9.73)
Upper GI | Calcit | placebo | 8 | 54 | 403 | 33 | 300 | 0.83(0.43, 1.57)
Upper GI | Estrog | placebo | 3 | 43 | 254 | 43 | 161 | 0.73(0.42, 1.26)
Upper GI | Estrog-proges | placebo | 2 | 17 | 125 | 125 | 517 | 0.55(0.3, 0.98)*
Upper GI | Ralox | placebo | 3 | 72 | 1375 | 28 | 804 | 1.1(0.68, 1.81)
Upper GI | PTH | placebo | 2 | 133 | 1383 | 49 | 691 | 1.39(0.98, 2)
Upper GI | calcium | placebo | 2 | 12 | 237 | 15 | 243 | 0.79(0.33, 1.87)
Upper GI | vitd | placebo | 2 | 3 | 75 | 10 | 75 | 0.27(0.04, 1.11)
Upper GI | Alendr | Etidro | 3 | 8 | 132 | 1 | 105 | 8.13(1.04, 371)*
Upper GI | Alendr | Pamidr | 1 | 2 | 21 | 0 | 19 | Inf+(0.17, Inf+)
Upper GI | Alendr | Risedr | 3 | 164 | 1259 | 157 | 1288 | 1.08(0.85, 1.39)
Upper GI | Risedr | Zoledr | 1 | 3 | 15 | 0 | 15 | Inf+(0.43, Inf+)
Upper GI | Alendr | Calcit | 4 | 46 | 413 | 9 | 288 | 3.65(1.72, 8.66)*
Upper GI | Alendr | Estrog | 4 | 61 | 255 | 45 | 306 | 1.82(1.12, 2.99)*
Upper GI | Alendr | Estrog-proges | 1 | 256 | 997 | 17 | 110 | 1.89(1.09, 3.45)*
Upper GI | Alendr | Ralox | 4 | 209 | 1218 | 176 | 1214 | 1.22(0.97, 1.53)
Upper GI | Alendr | vitd | 7 | 63 | 411 | 53 | 364 | 1.22(0.78, 1.91)
Upper GI | Etidro | Estrog | 2 | 9 | 31 | 0 | 33 | Inf+(2.55, Inf+)*
Upper GI | Etidro | calcium | 5 | 33 | 222 | 17 | 230 | 2.14(1.11, 4.27)*
Upper GI | Ibandr | vitd | 2 | 24 | 110 | 26 | 109 | 0.89(0.45, 1.76)
Upper GI | Risder | Estrog-proges | 1 | 3 | 15 | 0 | 15 | Inf+(0.43, Inf+)
Upper GI | Calcit | PTH | 2 | 20 | 86 | 10 | 81 | 2.02(0.82, 5.26)
Reflux and Esophageal | Alendr | placebo | 27 | 850 | 10400 | 719 | 8719 | 1.11(0.99, 1.23)
Reflux and Esophageal | Ibandr | placebo | 2 | 36 | 2445 | 12 | 1137 | 1.35(0.68, 2.88)
Reflux and Esophageal | Pamidr | placebo | 3 | 7 | 211 | 3 | 133 | 1.49(0.33, 9.24)
Reflux and Esophageal | Risedr | placebo | 13 | 159 | 8991 | 107 | 5310 | 0.9(0.69, 1.17)
Reflux and Esophageal | Calcit | placebo | 1 | 0 | 123 | 4 | 58 | 0(0, 0.69)*
Reflux and Esophageal | Estrog | placebo | 2 | 34 | 236 | 40 | 143 | 0.68(0.37, 1.24)
Reflux and Esophageal | Estrog-proges | placebo | 1 | 0 | 110 | 22 | 502 | 0(0, 0.81)*
Reflux and Esophageal | Alendr | Etidro | 1 | 1 | 70 | 0 | 36 | Inf+(0.01, Inf+)
Reflux and Esophageal | Alendr | Risedr | 3 | 19 | 1259 | 20 | 1288 | 0.97(0.49, 1.93)
Reflux and Esophageal | Alendr | Calcit | 1 | 3 | 118 | 0 | 123 | Inf+(0.43, Inf+)
Reflux and Esophageal | Alendr | Estrog | 2 | 51 | 185 | 34 | 236 | 2.03(1.15, 3.64)*
Reflux and Esophageal | Alendr | Estrog-proges | 1 | 47 | 997 | 0 | 110 | Inf+(1.39, Inf+)*
Reflux and Esophageal | Alendr | Ralox | 1 | 6 | 223 | 5 | 233 | 1.26(0.32, 5.3)
Reflux and Esophageal | Alendr | vitd | 2 | 6 | 144 | 12 | 109 | 0.45(0.13, 1.38)
Diarrhea | Alendr | placebo | 8 | 17 | 442 | 15 | 407 | 1.03(0.46, 2.35)
Diarrhea | Etidro | placebo | 4 | 4 | 138 | 13 | 142 | 0.3(0.07, 1)
Diarrhea | Ibandr | placebo | 2 | 41 | 309 | 3 | 111 | 4.87(1.48, 25.3)*
Diarrhea | Pamidr | placebo | 2 | 9 | 126 | 5 | 95 | 0.97(0.27, 3.94)
Diarrhea | Risedr | placebo | 5 | 38 | 538 | 34 | 352 | 0.94(0.53, 1.67)
Diarrhea | Calcit | placebo | 2 | 1 | 45 | 0 | 49 | Inf+(0.03, Inf+)
Diarrhea | Ralox | placebo | 1 | 1 | 102 | 6 | 102 | 0.16(0, 1.35)
Diarrhea | Alendr | Etidro | 1 | 1 | 46 | 0 | 53 | Inf+(0.03, Inf+)
Diarrhea | Alendr | Ralox | 1 | 27 | 716 | 11 | 707 | 2.48(1.18, 5.58)*
Diarrhea | Alendr | vitd | 1 | 4 | 68 | 3 | 66 | 1.31(0.21, 9.3)
Diarrhea | Etidro | calcium | 3 | 20 | 127 | 16 | 128 | 1.29(0.59, 2.85)
Diarrhea | Ibandr | vitd | 2 | 6 | 110 | 4 | 109 | 1.51(0.35, 7.46)
Elevated Transaminase | Alendr | placebo | 4 | 4 | 424 | 0 | 231 | Inf+(0.51, Inf+)
Elevated Transaminase | Pamidr | placebo | 1 | 1 | 51 | 2 | 50 | 0.48(0.01, 9.57)
Elevated Transaminase | Calcit | placebo | 1 | 1 | 75 | 0 | 71 | Inf+(0.02, Inf+)
Elevated Transaminase | Alendr | Calcit | 1 | 1 | 140 | 1 | 75 | 0.53(0.01, 42.4)
Elevated Transaminase | Calcit | PTH | 1 | 1 | 29 | 0 | 34 | Inf+(0.03, Inf+)
Hepatobiliary | Alendr | placebo | 1 | 0 | 140 | 1 | 71 | 0(0, 19.8)
Hepatobiliary | Pamidr | placebo | 1 | 0 | 51 | 1 | 50 | 0(0, 38.2)
Hepatobiliary | Calcit | placebo | 2 | 2 | 243 | 1 | 154 | 1.25(0.06, 76.3)
Hepatobiliary | Estrog | placebo | 1 | 11 | 723 | 12 | 1293 | 1.65(0.66, 4.11)
Hepatobiliary | Estrog-proges | placebo | 1 | 84 | 1380 | 62 | 1383 | 1.38(0.97, 1.97)
Hepatobiliary | Ralox | placebo | 1 | 130 | 5129 | 66 | 2576 | 0.99(0.73, 1.36)
GI (serious) | Alendr | placebo | 20 | 290 | 8656 | 202 | 7566 | 1.01(0.83, 1.24)
GI (serious) | Etidro | placebo | 7 | 254 | 8226 | 383 | 16249 | 1.32(1.12, 1.55)*
GI (serious) | Ibandr | placebo | 3 | 96 | 4357 | 61 | 2087 | 0.77(0.55, 1.08)
GI (serious) | Pamidr | placebo | 4 | 14 | 135 | 3 | 116 | 3.63(0.94, 20.6)
GI (serious) | Risedr | placebo | 12 | 169 | 8508 | 153 | 4721 | 0.93(0.72, 1.19)
GI (serious) | Ralox | placebo | 1 | 1 | 202 | 1 | 100 | 0.49(0.01, 39.1)
GI (serious) | Alendr | Etidro | 2 | 1 | 86 | 1 | 52 | 0.72(0.01, 59.4)
GI (serious) | Alendr | Pamidr | 1 | 5 | 21 | 2 | 19 | 2.59(0.36, 30.9)
GI (serious) | Alendr | Risedr | 2 | 1 | 739 | 3 | 755 | 0.34(0.01, 4.23)
GI (serious) | Alendr | Ralox | 1 | 1 | 223 | 0 | 233 | Inf+(0.03, Inf+)
GI (serious) | Alendr | vitd | 3 | 4 | 249 | 1 | 214 | 3.61(0.35, 182)
Upper GI Perforations, Ulcers or Bleeds (excl | Alendr | placebo | 12 | 170 | 5388 | 102 | 4543 | 0.88(0.66, 1.18)
Upper GI Perforations, Ulcers or Bleeds (excl | Etidro | placebo | 3 | 123 | 8066 | 186 | 16083 | 1.32(1.04, 1.67)*
Upper GI Perforations, Ulcers or Bleeds (excl | Ibandr | placebo | 2 | 12 | 2445 | 17 | 1137 | 0.33(0.14, 0.74)*
Upper GI Perforations, Ulcers or Bleeds (excl | Pamidr | placebo | 3 | 5 | 102 | 3 | 100 | 1.67(0.31, 11.2)
Upper GI Perforations, Ulcers or Bleeds (excl | Risedr | placebo | 7 | 14 | 2011 | 12 | 1406 | 0.64(0.27, 1.53)
Upper GI Perforations, Ulcers or Bleeds (excl | Alendr | Pamidr | 1 | 5 | 21 | 2 | 19 | 2.59(0.36, 30.9)
Upper GI Perforations, Ulcers or Bleeds (excl | Alendr | Risedr | 2 | 1 | 739 | 3 | 755 | 0.34(0.01, 4.23)
Upper GI Perforations, Ulcers or Bleeds (excl | Alendr | vitd | 2 | 3 | 179 | 1 | 180 | 3.06(0.24, 162)
Death due to PUBs | Alendr | Risedr | 1 | 0 | 520 | 1 | 533 | 0(0, 40)
Upper GI (serious) | Alendr | placebo | 2 | 1 | 449 | 2 | 454 | 0.5(0.01, 9.67)
Upper GI (serious) | Etidro | placebo | 3 | 5 | 133 | 7 | 139 | 0.75(0.18, 2.84)
Upper GI (serious) | Risedr | placebo | 2 | 122 | 844 | 119 | 844 | 1.02(0.77, 1.37)
Upper GI (serious) | Alendr | Ralox | 1 | 1 | 223 | 0 | 233 | Inf+(0.03, Inf+)
Esophogeal (serious) | Alendr | placebo | 8 | 49 | 6735 | 33 | 6433 | 1.42(0.89, 2.29)
Esophogeal (serious) | Etidro | placebo | 1 | 126 | 7977 | 190 | 15954 | 1.33(1.05, 1.68)*
Esophogeal (serious) | Ibandr | placebo | 1 | 5 | 1954 | 2 | 975 | 1.25(0.2, 13.1)
Esophogeal (serious) | Pamidr | placebo | 1 | 9 | 33 | 0 | 16 | Inf+(1.11, Inf+)*
Esophogeal (serious) | Risedr | placebo | 6 | 26 | 7242 | 19 | 3653 | 0.69(0.37, 1.32)
Esophogeal (serious) | Alendr | Etidro | 1 | 1 | 70 | 0 | 36 | Inf+(0.01, Inf+)
Esophogeal (serious) | Alendr | vitd | 1 | 1 | 70 | 0 | 34 | Inf+(0.01, Inf+)
Hepatobiliary (serious) | Alendr | Etidro | 1 | 0 | 16 | 1 | 16 | 0(0, 39)
Death due to Hepatobiliary | Alendr | Etidro | 1 | 0 | 16 | 1 | 16 | 0(0, 39)
Musculoskeletal | Alendr | placebo | 13 | 764 | 1975 | 396 | 1186 | 1.05(0.88, 1.27)
Musculoskeletal | Etidro | placebo | 6 | 42 | 245 | 36 | 243 | 1.24(0.72, 2.14)
Musculoskeletal | Ibandr | placebo | 5 | 1304 | 2969 | 578 | 1328 | 1.16(1, 1.34)
Musculoskeletal | Pamidr | placebo | 4 | 37 | 191 | 19 | 117 | 1.24(0.6, 2.64)
Musculoskeletal | Risedr | placebo | 9 | 224 | 992 | 243 | 673 | 0.4(0.29, 0.54)*
Musculoskeletal | Zoledr | placebo | 3 | 722 | 4236 | 166 | 3986 | 4.52(3.78, 5.43)*
Musculoskeletal | Calcit | placebo | 2 | 1 | 48 | 2 | 46 | 0.48(0.01, 9.28)
Musculoskeletal | Estrog | placebo | 6 | 93 | 1249 | 92 | 1631 | 0.84(0.6, 1.19)
Musculoskeletal | Estrog-proges | placebo | 1 | 62 | 110 | 299 | 502 | 0.88(0.57, 1.36)
Musculoskeletal | Ralox | placebo | 9 | 128 | 2398 | 52 | 1467 | 1.66(1.18, 2.38)*
Musculoskeletal | PTH | placebo | 1 | 16 | 1093 | 5 | 544 | 1.6(0.56, 5.62)
Musculoskeletal | Alendr | Estrog | 1 | 2 | 30 | 0 | 30 | Inf+(0.19, Inf+)
Musculoskeletal | Alendr | Estrog-proges | 1 | 627 | 997 | 62 | 110 | 1.31(0.86, 1.99)
Musculoskeletal | Alendr | Ralox | 1 | 2 | 33 | 3 | 33 | 0.65(0.05, 6.09)
Musculoskeletal | Alendr | PTH | 2 | 98 | 174 | 56 | 175 | 3.84(2.22, 6.8)*
Musculoskeletal | Alendr | vitd | 1 | 5 | 68 | 4 | 66 | 1.23(0.25, 6.49)
Musculoskeletal | Etidro | calcium | 1 | 2 | 15 | 0 | 11 | Inf+(0.14, Inf+)
Musculoskeletal | Ibandr | vitd | 2 | 14 | 110 | 8 | 109 | 1.83(0.68, 5.26)
Musculoskeletal | Calcit | PTH | 1 | 5 | 57 | 2 | 47 | 2.15(0.33, 23.6)
Musculoskeletal | Ralox | Estrog | 3 | 45 | 927 | 13 | 735 | 2.44(1.27, 5.02)*
Arthritis and Arthralgias | Alendr | placebo | 3 | 5 | 165 | 11 | 160 | 0.41(0.1, 1.38)
Arthritis and Arthralgias | Etidro | placebo | 1 | 12 | 75 | 10 | 77 | 1.27(0.47, 3.55)
Arthritis and Arthralgias | Risedr | placebo | 6 | 30 | 526 | 34 | 384 | 0.51(0.29, 0.92)*
Arthritis and Arthralgias | Zoledr | placebo | 3 | 303 | 4236 | 92 | 3986 | 2.98(2.33, 3.84)*
Arthritis and Arthralgias | Calcit | placebo | 2 | 1 | 48 | 1 | 46 | 0.95(0.01, 74.8)
Arthritis and Arthralgias | Estrog | placebo | 3 | 58 | 1001 | 67 | 1391 | 0.92(0.61, 1.39)
Arthritis and Arthralgias | Etidro | calcium | 1 | 1 | 15 | 0 | 11 | Inf+(0.02, Inf+)
Arthritis and Arthralgias | Ibandr | vitd | 1 | 8 | 58 | 4 | 57 | 2.11(0.52, 10.2)
Myalgias, Cramps and Limb Pain | Alendr | placebo | 3 | 5 | 97 | 3 | 97 | 1.7(0.32, 11.2)
Myalgias, Cramps and Limb Pain | Ibandr | placebo | 2 | 191 | 2383 | 39 | 1106 | 2.25(1.57, 3.29)*
Myalgias, Cramps and Limb Pain | Pamidr | placebo | 1 | 0 | 79 | 1 | 42 | 0(0, 20.7)
Myalgias, Cramps and Limb Pain | Risedr | placebo | 1 | 3 | 17 | 2 | 17 | 1.58(0.16, 21.7)
Myalgias, Cramps and Limb Pain | Zoledr | placebo | 3 | 413 | 4236 | 71 | 3986 | 5.79(4.47, 7.6)*
Myalgias, Cramps and Limb Pain | Estrog | placebo | 1 | 10 | 268 | 4 | 87 | 0.8(0.22, 3.61)
Myalgias, Cramps and Limb Pain | Ralox | placebo | 2 | 12 | 135 | 5 | 135 | 2.52(0.8, 9.39)
Myalgias, Cramps and Limb Pain | Alendr | Estrog | 1 | 2 | 30 | 0 | 30 | Inf+(0.19, Inf+)
Myalgias, Cramps and Limb Pain | Alendr | Ralox | 1 | 0 | 33 | 3 | 33 | 0(0, 2.38)
Myalgias, Cramps and Limb Pain | Alendr | PTH | 1 | 12 | 101 | 4 | 102 | 3.29(0.95, 14.5)
Myalgias, Cramps and Limb Pain | Alendr | vitd | 1 | 3 | 68 | 3 | 66 | 0.97(0.13, 7.51)
Myalgias, Cramps and Limb Pain | Ibandr | vitd | 1 | 6 | 52 | 4 | 52 | 1.56(0.34, 8.01)
Myalgias, Cramps and Limb Pain | Calcit | PTH | 1 | 5 | 57 | 1 | 47 | 4.37(0.46, 214)
Dermatologic | Alendr | placebo | 6 | 357 | 1464 | 188 | 718 | 0.97(0.78, 1.21)
Dermatologic | Etidro | placebo | 1 | 1 | 51 | 0 | 51 | Inf+(0.03, Inf+)
Dermatologic | Ibandr | placebo | 3 | 465 | 2463 | 242 | 1159 | 0.91(0.76, 1.09)
Dermatologic | Pamidr | placebo | 4 | 2 | 207 | 1 | 131 | 1.29(0.07, 78.9)
Dermatologic | Risedr | placebo | 2 | 5 | 187 | 2 | 85 | 2.08(0.31, 23.8)
Dermatologic | Calcit | placebo | 8 | 56 | 305 | 9 | 276 | 6.13(2.81, 14.9)*
Dermatologic | Estrog | placebo | 2 | 164 | 294 | 63 | 111 | 0.82(0.5, 1.33)
Dermatologic | Estrog-proges | placebo | 2 | 35 | 146 | 170 | 541 | 0.82(0.51, 1.28)
Dermatologic | Ralox | placebo | 1 | 2 | 102 | 0 | 102 | Inf+(0.19, Inf+)
Dermatologic | Tamox | placebo | 1 | 1 | 23 | 1 | 23 | 1(0.01, 82)
Dermatologic | Testos | placebo | 2 | 36 | 50 | 15 | 52 | 8.64(2.94, 29.7)*
Dermatologic | PTH | placebo | 1 | 5 | 10 | 1 | 13 | 10.6(0.88, 613)
Dermatologic | Alendr | Estrog-proges | 1 | 321 | 997 | 31 | 110 | 1.21(0.77, 1.94)
Dermatologic | Alendr | vitd | 1 | 2 | 68 | 2 | 66 | 0.97(0.07, 13.8)
Dermatologic | Etidro | calcium | 1 | 1 | 15 | 0 | 11 | Inf+(0.02, Inf+)
Dermatologic | Calcit | PTH | 2 | 4 | 86 | 4 | 81 | 0.85(0.15, 4.81)
Dermatologic | calcium | vitd | 1 | 1 | 29 | 2 | 34 | 0.58(0.01, 11.6)
Injection/Application Site Reactions | Ibandr | placebo | 1 | 46 | 1912 | 1 | 950 | 23.4(3.98, 945)*
Injection/Application Site Reactions | Calcit | placebo | 1 | 3 | 24 | 0 | 21 | Inf+(0.37, Inf+)
Injection/Application Site Reactions | Estrog | placebo | 1 | 147 | 268 | 51 | 87 | 0.86(0.51, 1.44)
Injection/Application Site Reactions | PTH | placebo | 1 | 5 | 10 | 1 | 13 | 10.6(0.88, 613)
Respiratory | Alendr | placebo | 3 | 810 | 1183 | 435 | 637 | 0.86(0.68, 1.09)
Respiratory | Ibandr | placebo | 3 | 1191 | 2463 | 577 | 1159 | 0.98(0.85, 1.14)
Respiratory | Estrog | placebo | 1 | 14 | 723 | 29 | 1293 | 0.86(0.42, 1.7)
Respiratory | Estrog-proges | placebo | 1 | 78 | 110 | 387 | 502 | 0.72(0.45, 1.19)
Respiratory | Testos | placebo | 2 | 2 | 78 | 1 | 78 | 2.01(0.1, 119)
Respiratory | PTH | placebo | 1 | 0 | 8 | 1 | 8 | 0(0, 39)
Respiratory | Alendr | Estrog-proges | 1 | 744 | 997 | 78 | 110 | 1.21(0.75, 1.89)
Respiratory | Calcit | PTH | 2 | 5 | 86 | 3 | 81 | 1.47(0.27, 9.84)
Renal | Etidro | placebo | 2 | 1 | 108 | 0 | 115 | Inf+(0.03, Inf+)
Renal | Zoledr | placebo | 2 | 205 | 3921 | 167 | 3906 | 1.24(1, 1.53)
Renal | PTH | placebo | 1 | 16 | 1093 | 8 | 544 | 1(0.4, 2.7)
Renal | Ralox | Tamox | 1 | 13 | 9875 | 9 | 9872 | 1.44(0.57, 3.83)
Renal | Alendr | vitd | 1 | 21 | 74 | 30 | 75 | 0.6(0.28, 1.24)
Serious Renal | Zoledr | placebo | 1 | 1 | 32 | 0 | 30 | Inf+(0.02, Inf+)
Serious Renal | Alendr | vitd | 1 | 4 | 74 | 7 | 75 | 0.56(0.11, 2.31)
Neurologic (mild) | Alendr | placebo | 10 | 133 | 944 | 92 | 655 | 1.24(0.89, 1.73)
Neurologic (mild) | Etidro | placebo | 3 | 4 | 295 | 1 | 308 | 4.28(0.42, 211)
Neurologic (mild) | Ibandr | placebo | 3 | 582 | 2463 | 290 | 1159 | 0.95(0.81, 1.13)
Neurologic (mild) | Pamidr | placebo | 1 | 18 | 81 | 5 | 41 | 2.05(0.66, 7.66)
Neurologic (mild) | Risedr | placebo | 5 | 67 | 402 | 50 | 290 | 1.42(0.89, 2.27)
Neurologic (mild) | Zoledr | placebo | 3 | 280 | 3959 | 90 | 3942 | 3.26(2.55, 4.19)*
Neurologic (mild) | Calcit | placebo | 5 | 53 | 1059 | 24 | 430 | 0.96(0.56, 1.68)
Neurologic (mild) | Estrog | placebo | 3 | 67 | 371 | 54 | 191 | 0.89(0.54, 1.45)
Neurologic (mild) | Estrog-proges | placebo | 1 | 5 | 15 | 0 | 15 | Inf+(1.07, Inf+)*
Neurologic (mild) | Ralox | placebo | 2 | 9 | 516 | 14 | 518 | 0.64(0.24, 1.6)
Neurologic (mild) | PTH | placebo | 2 | 122 | 1383 | 77 | 691 | 0.76(0.56, 1.05)
Neurologic (mild) | calcium | placebo | 1 | 1 | 173 | 2 | 176 | 0.49(0.01, 9.48)
Neurologic (mild) | Ralox | Tamox | 1 | 7 | 9875 | 6 | 9872 | 1.17(0.34, 4.2)
Neurologic (mild) | Alendr | Estrog | 1 | 52 | 93 | 44 | 93 | 1.41(0.76, 2.62)
Neurologic (mild) | Alendr | Ralox | 1 | 0 | 33 | 1 | 33 | 0(0, 39)
Neurologic (mild) | Etidro | calcium | 2 | 2 | 100 | 2 | 102 | 1.01(0.07, 14.1)
Neurologic (mild) | Risder | Estrog-proges | 1 | 0 | 15 | 5 | 15 | 0(0, 0.93)*
Neurologic (mild) | Zoledr | Estrog-proges | 1 | 0 | 15 | 5 | 15 | 0(0, 0.93)*
Neurologic (mild) | Calcit | Estrog-proges | 1 | 0 | 25 | 1 | 25 | 0(0, 39)
Neurologic (mild) | Calcit | PTH | 2 | 23 | 86 | 8 | 81 | 3.15(1.23, 8.86)*
Neurologic (mild) | Ralox | Estrog | 1 | 10 | 495 | 18 | 513 | 0.57(0.23, 1.31)
Neurologic (mild) | calcium | vitd | 1 | 0 | 29 | 1 | 34 | 0(0, 45.7)
Headaches | Alendr | placebo | 6 | 37 | 641 | 24 | 403 | 1.01(0.57, 1.81)
Headaches | Etidro | placebo | 3 | 4 | 295 | 1 | 308 | 4.28(0.42, 211)
Headaches | Pamidr | placebo | 1 | 18 | 81 | 5 | 41 | 2.05(0.66, 7.66)
Headaches | Risedr | placebo | 4 | 31 | 245 | 23 | 236 | 1.36(0.73, 2.56)
Headaches | Zoledr | placebo | 2 | 273 | 3904 | 90 | 3891 | 3.18(2.48, 4.09)*
Headaches | Calcit | placebo | 3 | 45 | 1023 | 23 | 395 | 0.74(0.43, 1.31)
Headaches | Estrog | placebo | 2 | 23 | 278 | 12 | 98 | 0.62(0.28, 1.43)
Headaches | Estrog-proges | placebo | 1 | 5 | 15 | 0 | 15 | Inf+(1.07, Inf+)*
Headaches | Ralox | placebo | 1 | 1 | 33 | 0 | 33 | Inf+(0.03, Inf+)
Headaches | PTH | placebo | 2 | 73 | 1383 | 44 | 691 | 0.81(0.54, 1.23)
Headaches | calcium | placebo | 1 | 1 | 173 | 2 | 176 | 0.49(0.01, 9.48)
Headaches | Alendr | Ralox | 1 | 0 | 33 | 1 | 33 | 0(0, 39)
Headaches | Etidro | calcium | 2 | 2 | 100 | 2 | 102 | 1.01(0.07, 14.1)
Headaches | Risder | Estrog-proges | 1 | 0 | 15 | 5 | 15 | 0(0, 0.93)*
Headaches | Zoledr | Estrog-proges | 1 | 0 | 15 | 5 | 15 | 0(0, 0.93)*
Headaches | Calcit | PTH | 1 | 5 | 57 | 0 | 47 | Inf+(0.78, Inf+)
Headaches | Ralox | Estrog | 1 | 10 | 495 | 18 | 513 | 0.57(0.23, 1.31)
Headaches | calcium | vitd | 1 | 0 | 29 | 1 | 34 | 0(0, 45.7)
Cerebrovascular Events | Calcit | Estrog-proges | 1 | 0 | 25 | 1 | 25 | 0(0, 39)
Neurologic (serious) | Alendr | placebo | 3 | 1 | 83 | 1 | 82 | 0.98(0.01, 77.3)
Neurologic (serious) | Ibandr | placebo | 2 | 31 | 2062 | 23 | 980 | 0.65(0.37, 1.18)
Neurologic (serious) | Pamidr | placebo | 1 | 2 | 81 | 0 | 41 | Inf+(0.09, Inf+)
Neurologic (serious) | Zoledr | placebo | 1 | 107 | 3889 | 99 | 3876 | 1.08(0.81, 1.44)
Neurologic (serious) | Calcit | placebo | 1 | 2 | 37 | 2 | 38 | 1.03(0.07, 14.9)
Neurologic (serious) | Estrog | placebo | 3 | 185 | 6546 | 144 | 7226 | 1.34(1.07, 1.68)*
Neurologic (serious) | Estrog-proges | placebo | 2 | 235 | 9886 | 181 | 9485 | 1.28(1.05, 1.57)*
Neurologic (serious) | Ralox | placebo | 4 | 154 | 3131 | 62 | 1590 | 1.2(0.88, 1.65)
Neurologic (serious) | Tamox | placebo | 1 | 64 | 6681 | 57 | 6707 | 1.13(0.78, 1.64)
Neurologic (serious) | Testos | placebo | 1 | 1 | 24 | 0 | 24 | Inf+(0.03, Inf+)
Neurologic (serious) | Etidro | calcium | 1 | 0 | 14 | 1 | 14 | 0(0, 39)
Neurologic (serious) | Calcit | PTH | 1 | 1 | 57 | 1 | 47 | 0.82(0.01, 65.9)
Neurologic (serious) | Estrog | calcium | 1 | 0 | 15 | 1 | 14 | 0(0, 36.4)
Neurological Death | Zoledr | placebo | 1 | 20 | 3889 | 11 | 3876 | 1.82(0.83, 4.2)
Neurological Death | Tamox | placebo | 1 | 4 | 6681 | 3 | 6707 | 1.34(0.23, 9.14)
Cerebrovascular Events (serious) | Ibandr | placebo | 2 | 1 | 2062 | 1 | 980 | 0.32(0, 27.3)
Cerebrovascular Events (serious) | Pamidr | placebo | 1 | 2 | 81 | 0 | 41 | Inf+(0.09, Inf+)
Cerebrovascular Events (serious) | Zoledr | placebo | 1 | 87 | 3889 | 88 | 3876 | 0.98(0.72, 1.34)
Cerebrovascular Events (serious) | Calcit | placebo | 1 | 2 | 37 | 2 | 38 | 1.03(0.07, 14.9)
Cerebrovascular Events (serious) | Estrog | placebo | 3 | 185 | 6546 | 144 | 7226 | 1.34(1.07, 1.68)*
Cerebrovascular Events (serious) | Estrog-proges | placebo | 2 | 235 | 9886 | 181 | 9485 | 1.28(1.05, 1.57)*
Cerebrovascular Events (serious) | Ralox | placebo | 3 | 154 | 2929 | 61 | 1490 | 1.22(0.89, 1.68)
Cerebrovascular Events (serious) | Tamox | placebo | 1 | 60 | 6681 | 52 | 6707 | 1.16(0.79, 1.72)
Cerebrovascular Events (serious) | Testos | placebo | 1 | 1 | 24 | 0 | 24 | Inf+(0.03, Inf+)
Cerebrovascular Events (serious) | Etidro | calcium | 1 | 0 | 14 | 1 | 14 | 0(0, 39)
Cerebrovascular Events (serious) | Calcit | PTH | 1 | 1 | 57 | 1 | 47 | 0.82(0.01, 65.9)
Cerebrovascular Events (serious) | Estrog | calcium | 1 | 0 | 15 | 1 | 14 | 0(0, 36.4)
Cerebrovascular Death | Ralox | placebo | 1 | 6 | 2725 | 1 | 1286 | 2.84(0.34, 131)
Cerebrovascular Death | Tamox | placebo | 1 | 3 | 6681 | 3 | 6707 | 1(0.13, 7.5)
Metabolic | Alendr | placebo | 3 | 10 | 347 | 0 | 253 | Inf+(1.86, Inf+)*
Metabolic | Etidro | placebo | 1 | 0 | 169 | 1 | 180 | 0(0, 37.7)
Metabolic | Ibandr | placebo | 3 | 340 | 2463 | 154 | 1159 | 1.1(0.89, 1.36)
Metabolic | Pamidr | placebo | 4 | 2 | 82 | 0 | 82 | Inf+(0.19, Inf+)
Metabolic | Risedr | placebo | 1 | 22 | 157 | 10 | 54 | 0.72(0.3, 1.84)
Metabolic | Zoledr | placebo | 1 | 13 | 32 | 3 | 30 | 5.98(1.38, 37.2)*
Metabolic | Calcit | placebo | 3 | 10 | 144 | 8 | 151 | 1.6(0.49, 5.4)
Metabolic | PTH | placebo | 2 | 294 | 1103 | 14 | 557 | 14(8.09, 26.2)*
Metabolic | calcium | placebo | 2 | 4 | 237 | 5 | 243 | 0.84(0.16, 4.04)
Metabolic | vitd | placebo | 3 | 14 | 476 | 14 | 473 | 0.99(0.43, 2.28)
Metabolic | Alendr | Etidro | 1 | 0 | 46 | 1 | 53 | 0(0, 44.9)
Metabolic | Alendr | Calcit | 1 | 3 | 15 | 2 | 15 | 1.6(0.15, 22.3)
Metabolic | Alendr | PTH | 1 | 0 | 101 | 3 | 102 | 0(0, 2.43)
Metabolic | Alendr | vitd | 6 | 30 | 379 | 71 | 366 | 0.33(0.2, 0.54)*
Metabolic | Etidro | Estrog | 1 | 3 | 14 | 0 | 15 | Inf+(0.47, Inf+)
Metabolic | Etidro | calcium | 3 | 3 | 114 | 3 | 116 | 0.97(0.12, 7.6)
Metabolic | Ibandr | vitd | 2 | 2 | 110 | 9 | 109 | 0.21(0.02, 1.04)
Metabolic | Pamidr | calcium | 1 | 1 | 14 | 1 | 13 | 0.93(0.01, 78.4)
Metabolic | Calcit | PTH | 1 | 3 | 29 | 6 | 34 | 0.54(0.08, 2.87)
Metabolic | Calcit | vitd | 2 | 2 | 64 | 0 | 65 | Inf+(0.19, Inf+)
Metabolic | calcium | vitd | 1 | 1 | 29 | 8 | 34 | 0.12(0, 0.99)*
Hypercalcemia | Etidro | placebo | 2 | 4 | 179 | 5 | 190 | 0.71(0.1, 4.78)
Hypercalcemia | Calcit | placebo | 3 | 13 | 139 | 12 | 146 | 1.3(0.45, 3.76)
Hypercalcemia | PTH | placebo | 2 | 294 | 1103 | 14 | 557 | 14(8.09, 26.2)*
Hypercalcemia | calcium | placebo | 2 | 4 | 237 | 5 | 243 | 0.84(0.16, 4.04)
Hypercalcemia | Alendr | PTH | 1 | 0 | 101 | 3 | 102 | 0(0, 2.43)
Hypercalcemia | Alendr | vitd | 2 | 1 | 138 | 9 | 139 | 0.11(0, 0.79)*
Hypercalcemia | Etidro | Calcit | 1 | 4 | 10 | 5 | 10 | 0.68(0.08, 5.36)
Hypercalcemia | Etidro | calcium | 2 | 0 | 100 | 3 | 102 | 0(0, 2.25)
Hypercalcemia | Calcit | PTH | 1 | 0 | 29 | 2 | 34 | 0(0, 6.23)
Hypercalcemia | calcium | vitd | 1 | 1 | 29 | 8 | 34 | 0.12(0, 0.99)*
Hypercalciuria | Etidro | placebo | 1 | 9 | 10 | 10 | 10 | 0(0, 39)
Hypercalciuria | Calcit | placebo | 1 | 7 | 10 | 10 | 10 | 0(0, 2.26)
Hypercalciuria | vitd | placebo | 1 | 14 | 360 | 14 | 357 | 0.99(0.43, 2.28)
Hypercalciuria | Alendr | vitd | 3 | 11 | 210 | 38 | 207 | 0.25(0.11, 0.51)*
Hypercalciuria | Etidro | Calcit | 1 | 9 | 10 | 7 | 10 | 3.61(0.23, 225)
Hypercalciuria | Ibandr | vitd | 1 | 1 | 58 | 5 | 57 | 0.18(0, 1.73)
Hypercalciuria | Pamidr | calcium | 1 | 1 | 14 | 1 | 13 | 0.93(0.01, 78.4)
Hypocalcemia | Alendr | placebo | 2 | 9 | 301 | 0 | 207 | Inf+(1.6, Inf+)*
Hypocalcemia | Pamidr | placebo | 3 | 1 | 62 | 0 | 62 | Inf+(0.03, Inf+)
Hypocalcemia | Zoledr | placebo | 1 | 13 | 32 | 3 | 30 | 5.98(1.38, 37.2)*
Hypocalcemia | Calcit | placebo | 1 | 2 | 15 | 0 | 15 | Inf+(0.19, Inf+)
Hypocalcemia | Alendr | Calcit | 1 | 3 | 15 | 2 | 15 | 1.6(0.15, 22.3)
Hypocalcemia | Alendr | vitd | 1 | 3 | 15 | 0 | 15 | Inf+(0.43, Inf+)
Hypocalcemia | Calcit | vitd | 1 | 2 | 15 | 0 | 15 | Inf+(0.19, Inf+)
Genitourinary | Alendr | placebo | 3 | 371 | 1167 | 184 | 621 | 1.05(0.85, 1.32)
Genitourinary | Etidro | placebo | 1 | 0 | 10 | 1 | 10 | 0(0, 39)
Genitourinary | Ibandr | placebo | 3 | 405 | 2463 | 186 | 1159 | 1.06(0.87, 1.29)
Genitourinary | Pamidr | placebo | 1 | 11 | 21 | 11 | 19 | 0.8(0.19, 3.31)
Genitourinary | Risedr | placebo | 1 | 1 | 35 | 0 | 31 | Inf+(0.02, Inf+)
Genitourinary | Zoledr | placebo | 1 | 36 | 55 | 30 | 51 | 1.32(0.56, 3.14)
Genitourinary | Calcit | placebo | 1 | 0 | 10 | 1 | 10 | 0(0, 39)
Genitourinary | Estrog | placebo | 1 | 11 | 158 | 2 | 152 | 5.59(1.19, 52.7)*
Genitourinary | Estrog-proges | placebo | 1 | 99 | 110 | 168 | 502 | 17.8(9.21, 37.9)*
Genitourinary | Ralox | placebo | 4 | 10 | 638 | 6 | 379 | 1.39(0.43, 4.98)
Genitourinary | Testos | placebo | 2 | 23 | 88 | 13 | 87 | 2.04(0.9, 4.8)
Genitourinary | Alendr | Estrog-proges | 1 | 345 | 997 | 99 | 110 | 0.06(0.03, 0.11)*
Genitourinary | Alendr | vitd | 2 | 2 | 136 | 6 | 132 | 0.32(0.03, 1.8)
Genitourinary | Ralox | Estrog | 2 | 3 | 804 | 186 | 671 | 0.01(0, 0.03)*
Genitourinary | Ralox | Estrog-proges | 1 | 6 | 495 | 45 | 513 | 0.13(0.04, 0.3)*
Prostate | Ralox | placebo | 1 | 2 | 25 | 3 | 25 | 0.64(0.05, 6.19)
Prostate | Testos | placebo | 2 | 21 | 88 | 12 | 87 | 1.97(0.85, 4.77)
Nephrolithiasis | Alendr | placebo | 1 | 1 | 24 | 0 | 24 | Inf+(0.03, Inf+)
Nephrolithiasis | Etidro | placebo | 1 | 0 | 10 | 1 | 10 | 0(0, 39)
Nephrolithiasis | Calcit | placebo | 1 | 0 | 10 | 1 | 10 | 0(0, 39)
Nephrolithiasis | Alendr | vitd | 2 | 2 | 136 | 6 | 132 | 0.32(0.03, 1.8)
Infection | Alendr | placebo | 3 | 79 | 394 | 34 | 235 | 1.44(0.91, 2.33)
Infection | Etidro | placebo | 4 | 43 | 154 | 39 | 150 | 1.15(0.66, 2.01)
Infection | Ibandr | placebo | 1 | 2 | 150 | 1 | 30 | 0.39(0.02, 23.9)
Infection | Pamidr | placebo | 1 | 0 | 81 | 1 | 41 | 0(0, 19.7)
Infection | Risedr | placebo | 3 | 2 | 211 | 1 | 101 | 1.49(0.07, 93.4)
Infection | Zoledr | placebo | 3 | 329 | 4213 | 66 | 3965 | 4.92(3.75, 6.54)*
Infection | Estrog | placebo | 1 | 92 | 268 | 32 | 87 | 0.9(0.53, 1.54)
Infection | Ralox | placebo | 1 | 6 | 102 | 6 | 102 | 1(0.26, 3.89)
Infection | Testos | placebo | 1 | 0 | 54 | 1 | 54 | 0(0, 39)
Infection | Alendr | vitd | 1 | 24 | 74 | 19 | 75 | 1.41(0.65, 3.08)
Infection | Pamidr | calcium | 1 | 0 | 14 | 1 | 13 | 0(0, 36.2)
Infection | Calcit | PTH | 1 | 4 | 57 | 5 | 47 | 0.64(0.12, 3.16)
Infection | Ralox | Estrog | 1 | 26 | 495 | 22 | 513 | 1.24(0.66, 2.32)
Death due to Infection | Zoledr | placebo | 1 | 1 | 32 | 0 | 30 | Inf+(0.02, Inf+)
Death due to Infection | Pamidr | calcium | 1 | 0 | 14 | 1 | 13 | 0(0, 36.2)
Hematologic | Alendr | placebo | 5 | 4 | 336 | 2 | 336 | 2.01(0.29, 22.5)
Hematologic | Ibandr | placebo | 3 | 154 | 2463 | 66 | 1159 | 1.13(0.84, 1.55)
Hematologic | Pamidr | placebo | 2 | 1 | 97 | 1 | 59 | 0.5(0.01, 40.2)
Hematologic | Risedr | placebo | 3 | 4 | 588 | 0 | 514 | Inf+(0.57, Inf+)
Hematologic | Calcit | placebo | 2 | 0 | 234 | 2 | 149 | 0(0, 2.62)
Hematologic | Estrog | placebo | 5 | 110 | 6705 | 82 | 7385 | 1.38(1.02, 1.86)*
Hematologic | Estrog-proges | placebo | 3 | 187 | 9950 | 79 | 9549 | 2.3(1.76, 3.04)*
Hematologic | Ralox | placebo | 8 | 213 | 6902 | 46 | 3691 | 2.3(1.66, 3.25)*
Hematologic | Tamox | placebo | 1 | 56 | 6681 | 28 | 6707 | 2.02(1.26, 3.3)*
Hematologic | Testos | placebo | 2 | 6 | 74 | 1 | 73 | 6.3(0.73, 299)
Hematologic | Ralox | Tamox | 1 | 28 | 9875 | 32 | 9872 | 0.87(0.51, 1.5)
Hematologic | Alendr | Estrog | 1 | 1 | 93 | 2 | 93 | 0.5(0.01, 9.69)
Hematologic | Alendr | Ralox | 2 | 0 | 256 | 2 | 266 | 0(0, 5.44)
Hematologic | Etidro | Estrog | 1 | 0 | 66 | 2 | 66 | 0(0, 5.31)
Hematologic | Calcit | Estrog | 1 | 0 | 66 | 2 | 66 | 0(0, 5.31)
Hematologic | Calcit | PTH | 1 | 3 | 57 | 0 | 47 | Inf+(0.34, Inf+)
Hematologic | Estrog | vitd | 1 | 2 | 66 | 0 | 66 | Inf+(0.19, Inf+)
Hematologic | Ralox | Estrog | 1 | 0 | 495 | 5 | 513 | 0(0, 1.13)
Thromboembolic Events | Alendr | placebo | 2 | 1 | 126 | 0 | 126 | Inf+(0.03, Inf+)
Thromboembolic Events | Estrog | placebo | 4 | 105 | 6639 | 79 | 7319 | 1.36(1.01, 1.86)*
Thromboembolic Events | Estrog-proges | placebo | 3 | 176 | 9950 | 75 | 9549 | 2.27(1.72, 3.02)*
Thromboembolic Events | Ralox | placebo | 7 | 167 | 6878 | 41 | 3667 | 2.08(1.47, 3.02)*
Thromboembolic Events | Tamox | placebo | 1 | 35 | 6681 | 22 | 6707 | 1.6(0.91, 2.87)
Thromboembolic Events | Alendr | Estrog | 1 | 1 | 93 | 2 | 93 | 0.5(0.01, 9.69)
Thromboembolic Events | Alendr | Ralox | 2 | 0 | 256 | 2 | 266 | 0(0, 5.44)
Thromboembolic Events | Ralox | Estrog | 1 | 0 | 495 | 5 | 513 | 0(0, 1.13)
Pulmonary Embolism | Risedr | placebo | 1 | 1 | 151 | 0 | 77 | Inf+(0.01, Inf+)
Pulmonary Embolism | Estrog | placebo | 1 | 3 | 513 | 3 | 504 | 0.98(0.13, 7.37)
Pulmonary Embolism | Estrog-proges | placebo | 1 | 11 | 1380 | 4 | 1383 | 2.77(0.82, 12)
Pulmonary Embolism | Ralox | placebo | 2 | 24 | 5153 | 2 | 2600 | 6.26(1.55, 54.8)*
Pulmonary Embolism | Tamox | placebo | 1 | 21 | 6681 | 6 | 6707 | 3.52(1.37, 10.7)*
Pulmonary Death | Risedr | placebo | 1 | 1 | 151 | 0 | 77 | Inf+(0.01, Inf+)
Pulmonary Death | Ralox | placebo | 1 | 5 | 5129 | 0 | 2576 | Inf+(0.46, Inf+)
Pulmonary Death | Tamox | placebo | 1 | 3 | 6681 | 0 | 6707 | Inf+(0.41, Inf+)
Psychiatric | Alendr | placebo | 1 | 312 | 997 | 156 | 502 | 1.01(0.8, 1.28)
Psychiatric | Etidro | placebo | 1 | 1 | 53 | 0 | 54 | Inf+(0.03, Inf+)
Psychiatric | Zoledr | placebo | 1 | 0 | 32 | 1 | 30 | 0(0, 36.6)
Psychiatric | Estrog-proges | placebo | 1 | 36 | 110 | 156 | 502 | 1.08(0.67, 1.71)
Psychiatric | Tamox | placebo | 2 | 6676 | 6751 | 6706 | 6777 | 0.43(0.07, 1.87)
Psychiatric | Alendr | Estrog-proges | 1 | 312 | 997 | 36 | 110 | 0.94(0.61, 1.47)
Psychiatric | Ralox | Estrog | 1 | 0 | 495 | 7 | 513 | 0(0, 0.71)*
Depression | Etidro | placebo | 1 | 1 | 53 | 0 | 54 | Inf+(0.03, Inf+)
Depression | Tamox | placebo | 1 | 6674 | 6681 | 6706 | 6707 | 0.14(0, 1.11)
Psychiatric Death | Zoledr | placebo | 1 | 0 | 32 | 1 | 30 | 0(0, 36.6)
Immunologic | Alendr | placebo | 3 | 3 | 255 | 0 | 186 | Inf+(0.33, Inf+)
Immunologic | Etidro | placebo | 2 | 0 | 36 | 2 | 38 | 0(0, 5.62)
Immunologic | Zoledr | placebo | 2 | 3 | 42 | 5 | 40 | 0.52(0.07, 3.29)
Immunologic | PTH | placebo | 1 | 59 | 1093 | 1 | 544 | 31(5.31, 1247)*
Immunologic | Alendr | Calcit | 1 | 1 | 140 | 0 | 75 | Inf+(0.01, Inf+)
Immunologic | Alendr | Ralox | 1 | 1 | 33 | 0 | 33 | Inf+(0.03, Inf+)
Immunologic | Alendr | PTH | 1 | 0 | 73 | 3 | 73 | 0(0, 2.4)
Immunologic | Alendr | vitd | 2 | 15 | 134 | 13 | 132 | 1.2(0.49, 2.99)
Immunologic | Ralox | Estrog-proges | 1 | 2 | 495 | 3 | 513 | 0.69(0.06, 6.05)
Anaphylaxis | Etidro | placebo | 2 | 0 | 36 | 2 | 38 | 0(0, 5.62)
Graft Rejection | Zoledr | placebo | 2 | 3 | 42 | 5 | 40 | 0.52(0.07, 3.29)
Graft Rejection | Alendr | vitd | 2 | 15 | 134 | 13 | 132 | 1.2(0.49, 2.99)
Death due to Graft Rejection | Zoledr | placebo | 1 | 0 | 32 | 2 | 30 | 0(0, 4.96)
Sweats/Fever/Hot Flashes | Alendr | placebo | 8 | 19 | 444 | 24 | 396 | 0.69(0.35, 1.35)
Sweats/Fever/Hot Flashes | Etidro | placebo | 1 | 0 | 17 | 1 | 20 | 0(0, 45.9)
Sweats/Fever/Hot Flashes | Ibandr | placebo | 1 | 47 | 108 | 20 | 36 | 0.62(0.27, 1.41)
Sweats/Fever/Hot Flashes | Pamidr | placebo | 5 | 8 | 194 | 0 | 149 | Inf+(1.39, Inf+)*
Sweats/Fever/Hot Flashes | Risedr | placebo | 4 | 6 | 104 | 5 | 93 | 1.25(0.29, 5.63)
Sweats/Fever/Hot Flashes | Zoledr | placebo | 4 | 725 | 4251 | 125 | 4001 | 9.18(7.25, 11.8)*
Sweats/Fever/Hot Flashes | Calcit | placebo | 7 | 6 | 157 | 1 | 169 | 5.91(0.71, 274)
Sweats/Fever/Hot Flashes | Estrog | placebo | 2 | 25 | 251 | 49 | 245 | 0.43(0.25, 0.75)*
Sweats/Fever/Hot Flashes | Ralox | placebo | 11 | 443 | 2628 | 171 | 1617 | 1.31(1.07, 1.61)*
Sweats/Fever/Hot Flashes | Tamox | placebo | 3 | 65 | 168 | 7 | 111 | 10.5(4.38, 29.3)*
Sweats/Fever/Hot Flashes | Risedr | Zoledr | 1 | 0 | 15 | 12 | 15 | 0(0, 0.13)*
Sweats/Fever/Hot Flashes | Alendr | Estrog | 2 | 6 | 123 | 9 | 123 | 0.65(0.18, 2.13)
Sweats/Fever/Hot Flashes | Alendr | Ralox | 3 | 30 | 552 | 57 | 556 | 0.5(0.31, 0.82)*
Sweats/Fever/Hot Flashes | Etidro | calcium | 2 | 0 | 34 | 1 | 28 | 0(0, 28.6)
Sweats/Fever/Hot Flashes | Zoledr | Estrog-proges | 1 | 12 | 15 | 0 | 15 | Inf+(7.46, Inf+)*
Sweats/Fever/Hot Flashes | Calcit | PTH | 1 | 9 | 57 | 2 | 47 | 4.17(0.8, 41.7)
Sweats/Fever/Hot Flashes | Ralox | Estrog | 2 | 126 | 804 | 32 | 671 | 2.79(1.79, 4.45)*
Fever | Pamidr | placebo | 3 | 5 | 140 | 0 | 114 | Inf+(0.84, Inf+)
Fever | Zoledr | placebo | 2 | 660 | 4181 | 81 | 3935 | 9(7.1, 11.5)*
Hot Flashes | Alendr | placebo | 2 | 2 | 125 | 6 | 79 | 0.17(0.02, 1.01)
Hot Flashes | Calcit | placebo | 1 | 0 | 24 | 1 | 21 | 0(0, 34.1)
Hot Flashes | Estrog | placebo | 1 | 17 | 158 | 41 | 152 | 0.33(0.17, 0.63)*
Hot Flashes | Ralox | placebo | 5 | 409 | 1747 | 153 | 779 | 1.27(1.02, 1.58)*
Hot Flashes | Tamox | placebo | 2 | 6728 | 6801 | 6707 | 6770 | Inf+(9.92, Inf+)*
Hot Flashes | Ralox | Estrog | 1 | 121 | 309 | 17 | 158 | 5.32(3.02, 9.88)*
Flushing | Zoledr | placebo | 1 | 32 | 55 | 26 | 51 | 1.33(0.58, 3.09)
Flushing | Calcit | placebo | 3 | 5 | 85 | 0 | 86 | Inf+(0.92, Inf+)
Flushing | Ralox | placebo | 4 | 30 | 316 | 13 | 271 | 1.97(0.96, 4.27)
Flushing | Tamox | placebo | 2 | 18 | 48 | 7 | 48 | 3.71(1.24, 12.4)*
Flushing | Calcit | PTH | 1 | 6 | 57 | 0 | 47 | Inf+(1.02, Inf+)*
Weight Gain | Alendr | placebo | 1 | 6 | 93 | 8 | 93 | 0.73(0.2, 2.53)
Weight Gain | Pamidr | placebo | 1 | 1 | 33 | 0 | 16 | Inf+(0.01, Inf+)
Weight Gain | Estrog | placebo | 1 | 8 | 93 | 8 | 93 | 1(0.31, 3.21)
Weight Gain | Alendr | Estrog | 1 | 6 | 93 | 8 | 93 | 0.73(0.2, 2.53)
Weight Gain | Ralox | Estrog | 1 | 4 | 495 | 13 | 513 | 0.31(0.07, 1.02)
Pain | Alendr | placebo | 1 | 5 | 46 | 4 | 46 | 1.28(0.25, 6.91)
Pain | Calcit | PTH | 1 | 3 | 57 | 2 | 47 | 1.25(0.14, 15.5)
Gynecologic | Alendr | placebo | 2 | 11 | 123 | 12 | 123 | 0.91(0.35, 2.36)
Gynecologic | Etidro | placebo | 1 | 0 | 38 | 1 | 39 | 0(0, 40)
Gynecologic | Estrog | placebo | 7 | 301 | 1573 | 62 | 2045 | 7.18(5.31, 9.82)*
Gynecologic | Estrog-proges | placebo | 3 | 34 | 244 | 1 | 151 | 58.1(9.03, 2452)*
Gynecologic | Ralox | placebo | 8 | 129 | 6924 | 63 | 3446 | 1.07(0.77, 1.51)
Gynecologic | Tamox | placebo | 3 | 3725 | 6801 | 2333 | 6793 | 2.33(2.17, 2.5)*
Gynecologic | Estrog | Estrog-proges | 1 | 10 | 135 | 0 | 144 | Inf+(2.51, Inf+)*
Gynecologic | Ralox | Tamox | 1 | 20 | 9875 | 14 | 9872 | 1.43(0.69, 3.06)
Gynecologic | Alendr | Estrog | 2 | 9 | 133 | 48 | 133 | 0.1(0.04, 0.24)*
Gynecologic | Etidro | Estrog | 1 | 0 | 14 | | | .(., .)
Gynecologic | Calcit | Estrog-proges | 1 | 0 | 25 | 1 | 25 | 0(0, 39)
Gynecologic | Estrog | calcium | 1 | | | 0 | 14 | .(., .)
Gynecologic | Ralox | Estrog | 2 | 85 | 618 | 345 | 577 | 0.11(0.08, 0.14)*
Gynecologic | Ralox | Estrog-proges | 1 | 1 | 495 | 4 | 513 | 0.26(0.01, 2.62)
Upper Respiratory | Alendr | placebo | 2 | 3 | 164 | 3 | 104 | 1(0.13, 7.89)
Upper Respiratory | Calcit | placebo | 5 | 231 | 1367 | 48 | 584 | 1.95(1.38, 2.79)*
Upper Respiratory | Estrog | placebo | 1 | 26 | 268 | 16 | 87 | 0.48(0.23, 1.01)
Upper Respiratory | vitd | placebo | 1 | 9 | 101 | 7 | 101 | 1.28(0.38, 4.46)
Upper Respiratory | Alendr | Calcit | 1 | 0 | 118 | 6 | 123 | 0(0, 0.87)*
Upper Respiratory | Calcit | vitd | 2 | 9 | 73 | 0 | 68 | Inf+(2.04, Inf+)*
Breast Abnormality (other than Cancer) | Alendr | placebo | 4 | 25 | 335 | 18 | 212 | 1.34(0.65, 2.82)
Breast Abnormality (other than Cancer) | Estrog | placebo | 7 | 205 | 730 | 55 | 545 | 3.79(2.64, 5.5)*
Breast Abnormality (other than Cancer) | Estrog-proges | placebo | 3 | 75 | 115 | 29 | 118 | 7.42(3.79, 15.2)*
Breast Abnormality (other than Cancer) | Ralox | placebo | 8 | 63 | 1971 | 38 | 869 | 0.74(0.48, 1.15)
Breast Abnormality (other than Cancer) | Alendr | Estrog | 2 | 22 | 123 | 57 | 123 | 0.22(0.11, 0.42)*
Breast Abnormality (other than Cancer) | Alendr | Ralox | 1 | 0 | 33 | 1 | 33 | 0(0, 39)
Breast Abnormality (other than Cancer) | Etidro | Estrog | 2 | 0 | 80 | 11 | 81 | 0(0, 0.23)*
Breast Abnormality (other than Cancer) | Risder | Estrog-proges | 1 | 0 | 15 | 6 | 15 | 0(0, 0.67)*
Breast Abnormality (other than Cancer) | Zoledr | Estrog-proges | 1 | 0 | 15 | 6 | 15 | 0(0, 0.67)*
Breast Abnormality (other than Cancer) | Calcit | Estrog | 1 | 0 | 66 | 1 | 66 | 0(0, 39)
Breast Abnormality (other than Cancer) | Calcit | Estrog-proges | 1 | 0 | 25 | 2 | 25 | 0(0, 5.29)
Breast Abnormality (other than Cancer) | Estrog | calcium | 1 | 10 | 15 | 0 | 14 | Inf+(4, Inf+)*
Breast Abnormality (other than Cancer) | Estrog | vitd | 1 | 1 | 66 | 0 | 66 | Inf+(0.03, Inf+)
Breast Abnormality (other than Cancer) | Ralox | Estrog | 4 | 42 | 1048 | 257 | 790 | 0.09(0.07, 0.13)*
Cancer | Alendr | placebo | 2 | 1 | 81 | 0 | 81 | Inf+(0.03, Inf+)
Cancer | Etidro | placebo | 3 | 3 | 172 | 1 | 178 | 3.12(0.25, 165)
Cancer | Ibandr | placebo | 3 | 3 | 676 | 0 | 205 | Inf+(0.12, Inf+)
Cancer | Pamidr | placebo | 2 | 4 | 132 | 0 | 91 | Inf+(0.4, Inf+)
Cancer | Risedr | placebo | 1 | 0 | 35 | 1 | 31 | 0(0, 34.5)
Cancer | Calcit | placebo | 1 | 1 | 32 | 0 | 31 | Inf+(0.02, Inf+)
Cancer | Estrog | placebo | 5 | 415 | 12124 | 497 | 12742 | 0.86(0.75, 0.99)*
Cancer | Estrog-proges | placebo | 5 | 520 | 18492 | 469 | 17690 | 1.07(0.94, 1.22)
Cancer | Ralox | placebo | 5 | 20 | 6316 | 12 | 3088 | 0.86(0.4, 1.95)
Cancer | Tamox | placebo | 5 | 409 | 6919 | 653 | 6888 | 0.6(0.53, 0.69)*
Cancer | Testos | placebo | 2 | 3 | 78 | 1 | 78 | 3.1(0.24, 168)
Cancer | PTH | placebo | 3 | 25 | 1559 | 25 | 794 | 0.49(0.27, 0.9)*
Cancer | Ralox | Tamox | 1 | 97 | 9875 | 100 | 9872 | 0.97(0.72, 1.3)
Cancer | Alendr | vitd | 1 | 0 | 60 | 2 | 57 | 0(0, 5.04)
Cancer | Etidro | calcium | 1 | 0 | 14 | 1 | 14 | 0(0, 39)
Cancer | Estrog | calcium | 1 | 0 | 15 | 1 | 14 | 0(0, 36.4)
Gyn Cancer | Etidro | placebo | 1 | 1 | 75 | 0 | 77 | Inf+(0.03, Inf+)
Gyn Cancer | Estrog-proges | placebo | 4 | 87 | 18456 | 82 | 17651 | 1.01(0.74, 1.39)
Gyn Cancer | Ralox | placebo | 2 | 2 | 5231 | 1 | 2678 | 1.28(0.06, 78.8)
Gyn Cancer | Tamox | placebo | 1 | 53 | 6681 | 35 | 6707 | 1.52(0.97, 2.41)
Gyn Cancer | Etidro | calcium | 1 | 0 | 14 | 1 | 14 | 0(0, 39)
Gyn Cancer | Estrog | calcium | 1 | 0 | 15 | 1 | 14 | 0(0, 36.4)
Death due to GYN Cancer | Tamox | placebo | 1 | 12 | 6681 | 13 | 6707 | 0.93(0.39, 2.2)
Breast Cancer | Etidro | placebo | 1 | 1 | 38 | 0 | 39 | Inf+(0.03, Inf+)
Breast Cancer | Ibandr | placebo | 1 | 1 | 150 | 0 | 30 | Inf+(0.01, Inf+)
Breast Cancer | Estrog | placebo | 5 | 238 | 12124 | 312 | 12742 | 0.79(0.66, 0.93)*
Breast Cancer | Estrog-proges | placebo | 3 | 202 | 9922 | 152 | 9524 | 1.28(1.03, 1.6)*
Breast Cancer | Ralox | placebo | 2 | 4 | 5988 | 2 | 2862 | 0.71(0.1, 7.97)
Breast Cancer | Tamox | placebo | 3 | 254 | 6776 | 501 | 6802 | 0.49(0.42, 0.57)*
Death due to Breast Cancer | Estrog | placebo | 1 | 4 | 5310 | 8 | 5429 | 0.51(0.11, 1.91)
Death due to Breast Cancer | Estrog-proges | placebo | 1 | 3 | 8506 | 2 | 8102 | 1.43(0.16, 17.1)
Bone | Ralox | Tamox | 1 | 2 | 9875 | 3 | 9872 | 0.67(0.06, 5.82)
Lung | Etidro | placebo | 1 | 0 | 59 | 1 | 62 | 0(0, 41)
Lung | Pamidr | placebo | 1 | 1 | 81 | 0 | 41 | Inf+(0.01, Inf+)
Lung | Ralox | placebo | 2 | 1 | 5153 | 2 | 2600 | 0.39(0.01, 7.87)
Lung | Tamox | placebo | 1 | 28 | 6681 | 28 | 6707 | 1(0.57, 1.76)
Lung | Ralox | Tamox | 1 | 39 | 9875 | 28 | 9872 | 1.39(0.84, 2.35)
Death due to Lung Cancer | Ralox | placebo | 1 | 1 | 5129 | 0 | 2576 | Inf+(0.01, Inf+)
Death due to Lung Cancer | Tamox | placebo | 1 | 8 | 6681 | 11 | 6707 | 0.73(0.25, 1.99)
Colon | Pamidr | placebo | 1 | 1 | 51 | 0 | 50 | Inf+(0.03, Inf+)
Colon | Estrog | placebo | 1 | 61 | 5310 | 58 | 5429 | 1.08(0.74, 1.57)
Colon | Estrog-proges | placebo | 1 | 45 | 8506 | 67 | 8102 | 0.64(0.43, 0.95)*
Colon | Tamox | placebo | 1 | 16 | 6681 | 13 | 6707 | 1.24(0.56, 2.8)
Colon | Ralox | Tamox | 1 | 30 | 9875 | 31 | 9872 | 0.97(0.57, 1.65)
Death due to Colon Cancer | Tamox | placebo | 1 | 1 | 6681 | 1 | 6707 | 1(0.01, 78.8)
Esophageal Cancer | Ralox | placebo | 1 | 0 | 202 | 1 | 100 | 0(0, 19.3)
Esophageal Cancer | Ralox | Tamox | 1 | 0 | 9875 | 1 | 9872 | 0(0, 39)
Gastric | Risedr | placebo | 1 | 0 | 35 | 1 | 31 | 0(0, 34.5)
Gastric | Ralox | placebo | 1 | 1 | 202 | 0 | 100 | Inf+(0.01, Inf+)
Gastric | Tamox | placebo | 1 | 1 | 6681 | 2 | 6707 | 0.5(0.01, 9.64)
Gastric | Ralox | Tamox | 1 | 1 | 9875 | 3 | 9872 | 0.33(0.01, 4.15)
Gastrointestinal NOS | Ibandr | placebo | 1 | 2 | 491 | 0 | 162 | Inf+(0.06, Inf+)
Gastrointestinal NOS | Ralox | placebo | 1 | 2 | 5129 | 0 | 2576 | Inf+(0.09, Inf+)
Death due to GI | Ralox | placebo | 1 | 2 | 5129 | 0 | 2576 | Inf+(0.09, Inf+)
Death due to Cancer | Estrog | placebo | 1 | 110 | 5310 | 118 | 5429 | 0.95(0.73, 1.25)
Death due to Cancer | Estrog-proges | placebo | 2 | 123 | 9886 | 110 | 9485 | 1.08(0.82, 1.41)
Death due to Cancer | Ralox | placebo | 1 | 1 | 202 | 0 | 100 | Inf+(0.01, Inf+)
Death due to Cancer | Tamox | placebo | 1 | 8 | 6681 | 22 | 6707 | 0.36(0.14, 0.85)*
Special Senses | Alendr | placebo | 3 | 0 | 311 | 2 | 304 | 0(0, 5)
Special Senses | Ibandr | placebo | 3 | 320 | 2463 | 171 | 1159 | 0.9(0.73, 1.11)
Special Senses | Pamidr | placebo | 1 | 0 | 31 | 1 | 30 | 0(0, 37.7)
Special Senses | Ralox | placebo | 3 | 746 | 5364 | 407 | 2709 | 0.91(0.79, 1.04)
Special Senses | Tamox | placebo | 1 | 574 | 6681 | 507 | 6707 | 1.15(1.01, 1.3)*
Special Senses | Ralox | Tamox | 1 | 1 | 9875 | 0 | 9872 | Inf+(0.03, Inf+)
Special Senses | Alendr | Ralox | 1 | 0 | 33 | 1 | 33 | 0(0, 39)
Eye | Alendr | placebo | 2 | 0 | 86 | 1 | 80 | 0(0, 34.6)
Eye | Ibandr | placebo | 1 | 1 | 1912 | 0 | 950 | Inf+(0.01, Inf+)
Eye | Pamidr | placebo | 1 | 0 | 31 | 1 | 30 | 0(0, 37.7)
Eye | Ralox | placebo | 3 | 746 | 5364 | 407 | 2709 | 0.91(0.79, 1.04)
Eye | Tamox | placebo | 1 | 574 | 6681 | 507 | 6707 | 1.15(1.01, 1.3)*
Eye | Ralox | Tamox | 1 | 1 | 9875 | 0 | 9872 | Inf+(0.03, Inf+)
Eye | Alendr | Ralox | 1 | 0 | 33 | 1 | 33 | 0(0, 39)
Cataract | Ibandr | placebo | 1 | 1 | 1912 | 0 | 950 | Inf+(0.01, Inf+)
Cataract | Ralox | placebo | 1 | 745 | 5129 | 406 | 2576 | 0.91(0.8, 1.04)
Cataract | Tamox | placebo | 1 | 574 | 6681 | 507 | 6707 | 1.15(1.01, 1.3)*
Ear | Alendr | placebo | 1 | 0 | 225 | 1 | 224 | 0(0, 38.8)
Endocrine | Ibandr | placebo | 1 | 2 | 159 | 1 | 81 | 1.02(0.05, 60.9)
Endocrine | Estrog | placebo | 1 | 11 | 723 | 16 | 1293 | 1.23(0.51, 2.85)
Endocrine | Ralox | Tamox | 1 | 18 | 9875 | 8 | 9872 | 2.25(0.93, 5.99)
ENT | Alendr | placebo | 3 | 5 | 179 | 6 | 119 | 0.81(0.18, 3.49)
ENT | Calcit | placebo | 9 | 35 | 499 | 14 | 349 | 2.31(1.13, 4.99)*
ENT | Ralox | placebo | 1 | 17 | 102 | 20 | 102 | 0.82(0.37, 1.78)
ENT | Alendr | Calcit | 2 | 0 | 133 | 14 | 138 | 0(0, 0.29)*
ENT | Calcit | vitd | 1 | 2 | 15 | 0 | 15 | Inf+(0.19, Inf+)
ENT | calcium | vitd | 1 | 7 | 29 | 9 | 34 | 0.89(0.24, 3.2)
Hypertension | Alendr | placebo | 3 | 9 | 248 | 3 | 175 | 3.11(0.76, 18.2)
Hypertension | Ibandr | placebo | 1 | 0 | 1912 | 1 | 950 | 0(0, 19.4)
Hypertension | Estrog | placebo | 2 | 18 | 361 | 6 | 180 | 1.63(0.58, 5.26)
Hypertension | Ralox | placebo | 2 | 2 | 304 | 5 | 202 | 0.35(0.03, 2.22)
Hypertension | Alendr | Estrog | 1 | 5 | 93 | 6 | 93 | 0.82(0.19, 3.38)
Acute Phase Reactions | Ibandr | placebo | 1 | 9 | 100 | 0 | 26 | Inf+(0.52, Inf+)
Acute Phase Reactions | Pamidr | placebo | 1 | 5 | 9 | 6 | 8 | 0.44(0.03, 4.73)
Acute Phase Reactions | Ibandr | vitd | 1 | 1 | 52 | 0 | 52 | Inf+(0.03, Inf+)
Pulmonary | Alendr | placebo | 1 | 1 | 157 | 0 | 31 | Inf+(0.01, Inf+)
Pulmonary | Pamidr | placebo | 1 | 1 | 15 | 1 | 16 | 1.07(0.01, 89.6)
Pulmonary Death | Alendr | placebo | 1 | 1 | 157 | 0 | 31 | Inf+(0.01, Inf+)
Pulmonary Death | Pamidr | placebo | 1 | 1 | 15 | 1 | 16 | 1.07(0.01, 89.6)
Peripheral Vascular Disease | Etidro | placebo | 1 | 1 | 18 | 0 | 19 | Inf+(0.03, Inf+)
Peripheral Vascular Disease | Estrog-proges | placebo | 1 | 66 | 8506 | 73 | 8102 | 0.86(0.61, 1.22)
Death due to PVD | Etidro | placebo | 1 | 1 | 18 | 0 | 19 | Inf+(0.03, Inf+)