# Appendix D Excluded Studies

## REJECTED: Abstract review

1 Alendronate reduced days of bed rest and limited activity in postmenopausal women with osteoporosis and existing fractures. ACP Journal Club. 2000 Jul–2000 Aug 31; 133(1):14. Rec #: 1207
2 Alendronate safely reduced fractures in postmenopausal women with low bone mass density. ACP Journal Club. 1997 May–1997 Jun 30; 126:73. Rec #: 1236
3 Assessment of fracture risk and its application to screening for postmenopausal osteoporosis. Report of a WHO Study Group. World Health Organ Tech Rep Ser. 1994; 843:1–129. Rec #: 2981
4 Design of the Women's Health Initiative clinical trial and observational study. The Women's Health Initiative Study Group. Control Clin Trials. 1998 Feb; 19(1):61–109. Rec #: 2882
5 Drugs for prevention and treatment of postmenopausal osteoporosis. Med Lett Drugs Ther. 2000 Oct 16; 42(1090):97–100. Rec #: 2479
6 Effects of estrogen or estrogen/progestin regimens on heart disease risk factors in postmenopausal women. The Postmenopausal Estrogen/Progestin Interventions (PEPI) Trial. The Writing Group for the PEPI Trial. JAMA. 1995 Jan 18; 273(3):199–208. Rec #: 3560
7 Effects of hormone therapy on bone mineral density: results from the postmenopausal estrogen/progestin interventions (PEPI) trial. The Writing Group for the PEPI. JAMA. 1996 Nov 6; 276(17):1389–96. Rec #: 2885
8 Etidronate for postmenopausal osteoporosis. Med Lett Drugs Ther. 1990 Dec 14; 32(833):111–2. Rec #: 2574
9 Meta-analysis: Bone mineral density measurement predicts risk for fractures in women. ACP Journal Club. 1996 Sep–1996 Oct 31; 125:48. Rec #: 1241
10 Raloxifene for postmenopausal osteoporosis. Med Lett Drugs Ther. 1998 Mar 13; 40(1022):29–30. Rec #: 2622
11 Recommendations for the prevention and treatment of glucocorticoid-induced osteoporosis. American College of Rheumatology Task Force on Osteoporosis Guidelines. Arthritis Rheum. 1996 Nov; 39(11):1791–801. Rec #: 2927
12 Review: Etidronate decreases vertebral but not nonvertebral fractures in postmenopausal women. ACP Journal Club. 2002 May–2002 Jun 30; 136(3):98. Rec #: 1191
13 Risedronate. Drugs-Aging. 1998; 13(1):83–91; discussion 92. Rec #: 1525
14 Synthetic calcitonin for postmenopausal osteoporosis. Med Lett Drugs Ther. 1985 Jun 21; 27(690):53–4. Rec #: 2714
15 Vitamin D analogs appear superior to native form in preventing bone loss, fractures. Geriatrics and Aging. 2005; 8(3): 9. Rec #: 3469
16 Adachi, J. D.; Adarni, S.; Miller, P. D., and et al. Tolerability of risedronate in alendronate-intolerant postmenopausal women [abstract]. 2000; 43, (Suppl): S202 Abstract 815_. Rec #: 2965
17 Adachi JD, Rostom A. (1999). Metabolic bone disease in adults with inflammatory bowel disease. Inflamm Bowel Dis.
18 Adam M, Spacek P, Hulejova H, Galianova A, Blahos J. (1996). [Postmenopausal osteoporosis. Treatment with calcitonin and a diet rich in collagen proteins]. Casopis Lekaru Ceskych.
19 Adami S, Delmas P, Felsenberg D. (2002). Three-monthly 2 mg intravenous ibandronate bolus injections significantly increase bone mineral density in women with postmenopausl osteoporosis. Osteoporos Int.
20 Adami, S.; Orranell, S.; Lombardi, P.; Campagnoli, C.; Ferrari, A.; Marchesoni, D., and Balena, R. Prevention of early postmenopausal bone loss with cyclical etidronate: a double-blind, placebo-controlled study. IBMS Second Meeting; San Francisco, CA. Rec #: 3136
21 Agnusdei, D. ; Azria, M., and et al. Acute metabolic and analgesic effect of salmon calcitonin infusion in patients with metastatic bone disease. Rec #: 1812
22 Agnusdei D, Civitelli R, Camporeale A, Gennari C. (1990). Calcitonin and estrogens. Journal of Endocrinological Investigation.
23 Agnusdei D, Gonnelli S, Camporeale A, Batignani T, Nardi P, Ianes A, Gennari C. (1989). [Clinical efficacy of treatment with salmon calcitonin, administered intranasally for 1 year, in stabilized postmenopausal osteoporosis]. Minerva Endocrinologica.
24 Agnusdei, D. ; Gonnelli, S., and et al. Dose-response bioactivity of rectal salmon calcitonin in postmenopausal osteoporotic patients. Rec #: 1818
25 Aitken JM, Hart DM, Lindsay R. (1973). Oestrogen replacement therapy for prevention of osteoporosis after oophorectomy. Br Med J.
26 Aitken JM, Lindsay R, Hart DM. (1976). Long-term oestrogens for the prevention of post-menopausal osteoporosis. Postgrad Med J.
27 Akarirmak U, Tuzun F, Eskiyurt N, et al. (2000). Use and side effect profile of three different non-HRT treatments used in osteoporotic women (A preliminary study). Osteoporos Int.
28 Aktas, S.; Alparslan, N., and et al. A comparison of the effects of etidronate and calcitonin on postmenopausal osteoporosis. 1996. Rec #: 1617
29 Alexandersen P, Toussaint A, Christiansen C, Devogelaer JP, Roux C, Fechtenbaum J, Gennari C, Reginster JY. (2001). Ipriflavone in the treatment of postmenopausal osteoporosis: a randomized controlled trial. JAMA.
30 Amin S, La Valley MP, Simms RW, et al. (1998). A meta-analysis ranking efficacy of treatments for corticosteroid-induced osteoporosis (CSOP). Arthritis Rheum.
31 Amin S, Lavalley MP, Simms RW, Felson DT. (2002). The comparative efficacy of drug therapies used for the management of corticosteroid-induced osteoporosis: a meta-regression. J Bone Miner Res.
32 Amizuka N, Henderson JE, White JH, Karaplis AC, Goltzman D, Sasaki T, Ozawa H. (2000). Recent studies on the biological action of parathyroid hormone (PTH)-related peptide (PTHrP) and PTH/PTHrP receptor in cartilage and bone. Histol Histopathol.
33 Anderson C, Cape RD, Crilly RG, Hodsman AB, Wolfe BM. (1984). Preliminary observations of a form of coherence therapy for osteoporosis. Calcif Tissue Int.
34 Anderson GL, Manson J, Wallace R, Lund B, Hall D, Davis S, Shumaker S, Wang CY, Stein E, Prentice RL. (2003). Implementation of the Women's Health Initiative study design. Ann Epidemiol.
35 Annonymous. Biphosphonates in the treatment of osteoporosis. Wiener Medizinische Wochenschrift. 1996; 146(5):101. Rec #: 1436
36 Ansbacher, R. Proceedings of the breakfast and CE series held at the 2001 midyear clinical meeting of hte American Society of Health System Pharmacists [Web Page]. 2001; Accessed 2003 Dec 22. Available at: www.ashpadvantage.com. Rec #: 2931
37 Aris, R. M.; Ontjes, D. A.; Winders, A. W.; Blackwood, D., and Lester, G. E. Effect of pamidronate on bone biomarkers in post-transplant osteoporotic cycstic fibrosis patients [abstract]. 1998(Suppl 17): 364–5. Rec #: 3003
38 Astengo F, Della MA, Fontana L, Fuliano P, Bigolari M. (1994). Efficacy and safety of two elcatonin regimens in the treatment of osteoporosis. Curr Ther Res Clin Exp.
39 Avioli LV. (1998). The role of calcitonin in the prevention of osteoporosis. Endocrinol Metab Clin North Am.
40 Bandeira F, Ericksen EF, Szejnfeld V, et al. (2004). Positive correlations between early changes in biochemical markers of bone formation and volumetric BMD after teriparatide therapy: further evidence of diverging effects of alendronate and teriparatide on bone. Osteoporosis Int.
41 Baran DT. (2000). Osteoporosis: which current treatments reduce fracture risk?. Cleve Clin J Med.
42 Barrett-Connor E, Young R, Notelovitz M, Sullivan J, Wiita B, Yang HM, Nolan J. (1999). A two-year, double-blind comparison of estrogen-androgen and conjugated estrogens in surgically menopausal women. Effects on bone mineral density, symptoms and lipid profiles. The Journal of Reproductive Medicine.
43 Bartram SA, Francis RM, Thompson NP. (2001). A randomised trial of intravenous pamidronate and calcium &vitamin D in the treatment of osteoporosis associated with Crohn's disease (abstract). Gut.
44 Bauer, D. C. ; Ensrud, K., and Hochberg, M. Oral alendronate 10 mg daily does not cause serious symptomatic gastroduodenal ulcers and complications. Am College of Gastroenterology Annual Meeting; New York, New York. Rec #: 3143
45 Bech, P.; Munk-Jensen, N.; Obel, E. B.; Ulrich, L. G.; Eiken, P., and Nielsen, S. P. Combined versus sequential hormonal replacement therapy: a double-blind, placebo-controlled study on quality of life-related outcome measures. Psychother Psychosom. 1998 Jul–1998 Oct 31; 67(4–5):259–65. Rec #: 2906
46 Belch AR, Bergsagel DE, Wilson K, O'Reilly S, Wilson J, Sutton D, Pater J, Johnston D, Zee B. (1991). Effect of daily etidronate on the osteolysis of multiple myeloma. Journal of Clinical Oncology : Official Journal of the American Society of Clinical Oncology.
47 Bellometti, S.; Richelmi, P.; Gregotti, C., and Berte, F. Physical exercise and MPT are able to improve bone metabolism. Rec #: 1612
48 Berry S, Waldron T, Winquist E, Lukka H. (2006). The use of bisphosphonates in men with hormone-refractory prostate cancer: a systematic review of randomized trials. Can J Urol.
49 Bertolini G, Naliato P, Cruciatti A, et al. (1982). Treatment of senile and postmenopausal osteoporosis with synthetic calcitonin. Med-Geriatr.
50 Betancourt M, Wirfel KL, Raymond AK, Yasko AW, Lee J, Vassilopoulou-Sellin R. (2003). Osteosarcoma of bone in apatient with primary hyperparathyroidism: a case report. J Bone Miner Res.
51 Bettembuk P, Balogh A. (1999). [The effect of a one-year alendronate therapy on postmenopausal osteoporosis. (Results in Hungary of an international multicenter clinical study)]. Orvosi Hetilap.
52 Black DM, Arden NK, Palermo L, Pearson J, Cummings SR. (1999). Prevalent vertebral deformities predict hip fractures and new vertebral deformities but not wrist fractures. Study of Osteoporotic Fractures Research Group. J Bone Miner Res.
53 Black, D. M. ; Cummings, S. R.; Karpf, D. B.; Cauley, J.; Ensrud, K.; Genant, H. K.; Haskell, W.; Marcus, R.; Nevitt, M. C.; Ott, S. M.; Quandt, S. A.; Torner, J. C., and Thompson, D. Alendronate reduces the risk of vertebral and clinical fractures in women with existing vertebral fractures: Preliminary results of the Fracture Intervention Trial. Osteoporosis. 1996; 1996:Proceedings of the 1996 World Congress on Osteoporosis 315–319p. Rec #: 1929
54 Black, D. M. ; Cummings, S. R., and Thompson, D. The effect of alendronate on rates of vertebral and non-vertebral fractures in women with vertebral fractures: preliminary results of the fracture intervention trial. 1996. Rec #: 1938
55 Black DM, Rosen C, Greemspan S, et al. (2001). PTH and bisphosphonates in the treatment of osteoporosis: The PTH and alendronate (PaTH) trial. J Bone Miner Res.
56 Black DM, Rosen CJ, Palermo L, et al. (2004). The effect of 1 year of alendronate following 1 year of PTH 1–84: Second year results from the PTH and alendronate (PaTH) trial. J Bone Miner Res.
57 Black DM, Thompson DE. (1999). The effect of alendronate therapy on osteoporotic fracture in the vertebral fracture arm of the Fracture Intervention Trial. Int J Clin Pract Suppl.
58 Bockman RS. (1990). Etidronate for postmenopausal osteoporosis. N Engl J Med.
59 Bolanca S, Korsic M, Dekanic D, Cvijetic S. (1998). Effects of combined treatment with etidronate, nandrolone-decanoate and calcium on bone mineral density in postmenopausal women. Acta Med Croatica.
60 Bone, Tooth Society of Great Britain National Osteoporosis Society Royal College of Physicians. Glucocorticoid-induced osteoporosis: guidelines for prevention and treatment. Royal College of Physicians of London. 2001; 57. Rec #: 2978
61 Boniva. FDA Drug Approval Package. 2—3. Rec #: 3165
62 Bonnick S, Hochber M, Broy S, et al. (2005). Comparison of once-weekly alendronate and once-weekly risedronate in the osteoporotic subgroup from the FACT study. Osteoporos Int.
63 Bonnick S, Rosen C, Mako B, et al. (1998). Alendronate vs calcium for treatment of osteoporosis in postmenopausal women. Bone.
64 Bonnick SL. (1998). Investigation of postmenopausal osteoporosis: alendronate vs. calcium trial. Bone.
65 Bordier P, Kuntz D, Miravet L, Marie P. (1979). [Treatment of ordinary osteoporosis by the combination of salmon calcitonin-phosphorus and magnesium]. La Nouvelle Presse Medicale.
66 Borisov, N. N.; Doyle, J. J.; Klemes, A., and et al. Economic evaluation of the relationship between gastrointestinol events and bisphosphonate therapy: risedronate versus alendronate. Endocrine Practice. 2003 Mar–2003 Apr 30; 9(1):28. Rec #: 2078
67 Braga de Castro Machado A, Hannon R, Eastell R. (1999). Monitoring alendronate therapy for osteoporosis. J Bone Miner Res.
68 Brandi, M. L. Raloxifene reduces vertebral fracture risk in postmenopausal women with osteoporosis. Clin Exp Rheumatol. 2000 May–2000 Jun 30; 18(3):309–10. Rec #: 1633
69 Brixen K, Rejnmark L. Charles P. Mosekilde L. Effect of nasal calcitonin on bone mineral density (BMD) in postmenopausal osteoporosis - a dose response study. Rec #: 1531
70 Brown, J. P. ; Fortier, M.; Khan, A., and Rowe, T. An evidence-based review of the management of osteoporosis. J Soc Obstet Gynaecol Can. 2001 Apr; 1–7. Rec #: 1092
71 Brown JP, Josse RG. (2002). 2002 clinical practice guidelines for the diagnosis and management of osteoporosis in Canada. CMAJ.
72 Broy S, Saag K, Hochberg M, et al. (2005). Comparison of overall and upper gastrointestinal tolerability of once-weekly alendronate and risedronate across age subgroups: results from the FACT study. Osteoporos Int.
73 Buffo L, Rossini M, Buoncristiano A, Girardello S, Zamberlan N, Diani F, Adami S. (1996). [Diphosphonates: and alternative to estrogen therapy in postmenopausal osteoporosis. Experience with alendronate]. Minerva Ginecologica.
74 Burger H, de Laet CE, van Daele PL, Weel AE, Witteman JC, Hofman A, Pols HA. (1998). Risk factors for increased bone loss in an elderly population: the Rotterdam Study. Am J Epidemiol.
75 Buyukoren, A.; Baysal, B., and Turfanda, A. The efficacy of low-dose estrogen combined with calcitonin in preventing osteoporosis. Rec #: 1695
76 Byrne M, Nieschlag E. (2003). Testosterone replacement therapy in male hypogonadism. J Endocrinol Invest.
77 Canalis, E.; McCarthy, T. L., and Centrella, M. Differential effects of continuous and transient treatment with parathyroid hormone related peptide (PTHrp) on bone collagen synthesis. 1990 Apr; 126, (4): 1806–12. Rec #: 3027
78 Cantatore FP, Acquista CA, Pipitone V. (1999). Evaluation of bone turnover and osteoclastic cytokines in early rheumatoid arthritis treated with alendronate. The Journal of Rheumatology.
79 Caraceni, M. P.; Corghi, E.; Ortolani, S.; Dindelli, M.; Candotti, G., and Ferrari, A. Prevention of early postmenopausal bone loss. The effect of calcitonin (Staporos). Clin. 1988; TRIALS J. 25(6):401–405. Rec #: 1958
80 Carmina E, Di Fede G, Sferrazza C. (2003). Differences in early dynamics of serum bone markers in women with postmenopausal osteoporosis treated by alendronate or risedronate. J Bone Miner Res.
81 Cauley J, Lippman M, McNabb M, Secrest R, Cantor P. (2003). Raloxifene therapy and breast cancer risk reduction in postmenopausal women with osteopenia or osteoporosis. International Journal of Obstetrics & Gynecology.
82 Chapuy MC, Arlot ME, Duboeuf F, Brun J, Crouzet B, Arnaud S, Delmas PD, Meunier PJ. (1992). Vitamin D3 and calcium to prevent hip fractures in the elderly women. N Engl J Med.
83 Chavassieux, P.; Arlot, M. E., and et al. Effects at the basic structure unit level of long-term alendronate treatment in post-menopausal osteoporosis. 1996. Rec #: 1941
84 Chesnut CH, Harris ST. (1993). Short-term effect of alendronate on bone mass and bone remodeling in postmenopausal women. Osteoporos Int.
85 Chestnut CH. (1993). Calcitonin in the prevention and treatment of osteoporosis. Osteoporos Int.
86 Cheung WK, Honc F, Schoenfeld S, Knight R, Seaman J, Bowen AT, John V, Redalieu E, Chan K. (1994). A Single-Dose Bioavailability Study of Pamidronate Disodium after Oral Administration as Encapsulated Enteric-Coated Pellets, Enteric-Coated Tablets, and a Solution to Patients with Postmenopausal Osteoporosis. Am J Ther.
87 Chow R, Harrison JE, Notarius C. (1987). Effect of two randomised exercise programmes on bone mass of healthy postmenopausal women. British Medical Journal (Clinical Research Ed).
88 Chrischilles EA, Butler CD, Davis CS, Wallace RB. (1991). A model of lifetime osteoporosis impact. Arch Intern Med.
89 Christiansen C. (1988). Intranasal calcitonin for prevention and treatment of osteoporosis. Ann Chir Gynaecol.
90 Clemente PA, Cardama F, Armengol R, Goma MT. (1996). [ Effect of therapeutical association between hormone replacement therapy and cyclic intermittent therapy with etidronate about bone mineral content in women with postmenopausal osteoporosis. ]. Progresos De Obstetricia y Ginecología.
91 Coco, M.; Glicklich, D.; Burris, L.; Bognar I. ; Tellis, V., and Greenstein, S. Prospective randomised trial of IV pamidronate in renal transplant recipients: 6 and 12 month follow-up. 2002; 13, Programs and Abstracts:10. Rec #: 3061
92 Cohen, F.; Watts, S., and Beymer, K. Vaginal complaints in healthy postmenopausal women: data from a 3-year trial comparing raloxifene with conjugated estrogens or placebo [abstract]. The North American Menopause Society 9th Annual Meeting; Toronto. Rec #: 1129
93 Cokolic M, Hren R. (2002). Treatment of idiopathic osteoporosis in male patients using alendronate. Calcif Tissue Int.
94 Cole RC, Flaws JA, Bush TL. (1998). Effects of raloxifene in postmenopausal women. N Engl J Med.
95 Compston J. (2005). Prevention of vertebral fractures by strontium ranelate in postmenopausal women with osteoporosis. Osteoporos Int.
96 Condon JR, Nassim JR, Dent CE, Hilb A, Stainthorpe EM. (1978). Possible prevention and treatment of steroid-induced osteoporosis. Postgrad Med J.
97 Corrado F, Altavilla D, D'Anna R, Cancellieri F, Cannata ML. (2002). Effects of the phytoestrogen genistein and hormone replacement therapy on bone mineral density and metabolism in early post-menopausal women: a randomised double blind placebo-controlled study. Abstracts of Posters: 10th World Congress on Menopause: Climacteric.
98 Cosman F, Nieves J, Woelfert L, Shen V, Lindsay R. (1998). Alendronate does not block the anabolic effect of PTH in postmenopausal osteoporotic women. Journal of Bone and Mineral Research : the Official Journal of the American Society for Bone and Mineral Research.
99 Coster A, Dorst A, Umbach R, Ringe JD. (1999). Therapeutic intervention of Ibandronate by glucocorticoid-induced osteoporosis (GIOP). Zeitschrift Fur Rheumatologie.
100 Crandall C. (2005). Raloxifene reduced vertebral fractures and breast cancer regardless of hormone therapy use in women. Evidence-Based Medicine.
101 Crandell C. (2003). Parathyroid hormone increases lumbar spine bone mineral density and decreases vertebral fractures in osteoporosis. ACP J Club.
102 Cranney, A. and O'Donnell, S. Strontium Ranelate for preventing and treating postmenopausal osteoporosis [Protocol]. Cochrane Database of Systematic Reviews 2005;(3). 2005. Rec #: 2024
103 Cranney A, Tugwell P, Cummings S, Sambrook P, Adachi J, Silman AJ, Gillespie WJ, Felson DT, Shea B, Wells G. (1997). Osteoporosis clinical trials endpoints: candidate variables and clinimetric properties. J Rheumatol.
104 Cranney, A.; Welch, V.; Adachi, J. D.; Homik, J.; Shea, B.; Suarez-Almazor, M. E.; Tugwell, P., and Wells, G. Calcitonin for the treatment and prevention of corticosteroid-induced osteoporosis. Cochrane Database Syst Rev. 2000; (2):CD001983. Rec #: 2859
105 Cristallini S, Pedetti M, Donatelli C, Gregorio F, Filipponi P. (1993). [The effect of different “coherent”-type therapeutic plans on bone mineral density and on the incidence of vertebral fractures in advanced osteoporosis]. Recenti Progressi in Medicina.
106 Cummings S. (2004). Summary—curing osteoporosis. J Musculoskelet Neuronal Interact.
107 Cummings SR, Norton L, Eckert S, Grady D, Cauley J, Knickerbocker R, et al. (1998). Raloxifine reduces the risk of breast cancer and may decrease the risk of endometrial cancer in post-menopausal women. Two year finding from the multiple outcomes of raloxifine evaluation (MORE) trial [abstrat]. Proc ASCO.
108 Cutolo, M.; Barisone, G.; Seriolo, B., and Accardo, S. Juxta-articular osteoporosis in rheumatoid arthritis: Reversal by local subcutaneous calcitonin. Curr. 1990; THER. RES. CLIN. EXP. 48(6):1126–1135. Rec #: 1917
109 Daoud M, Licata AA. (1997). Side effect profile of alendronate in clinical practice. J Bone Miner Res.
110 Daoudi Y, Riou C, Cheverry C, Pawlotsky Y, Langlais F. (1992). Comparative study of two calcitonins in prevention of post-traumatic reflex dystrophy. <ORIGINAL> ETUDE COMPARATIVE DE DEUX CALCITONINES DANS LA PREVENTION DES ALGODYSTROPHIES POST-TRAUMATIQUES. J Pharm Clin.
111 de Nijs R, Jacobs J, Algra A, et al. (2004). Alendronate is more effective than alphacalcidol in preventing glucocorticoid-induced osteoporosis. J Bone Miner Res.
112 Deal C. (2004). The use of intermittent human parathyroid hormone as a treatment for osteoporosis. Curr Rheumatol Rep.
113 Deal CL, Draper MW. (2006). Raloxifene: A selective estrogen-receptor modulator for postmenopausal osteoporosis - A clinical update on efficacy and safety. Women's Health.
114 Delmas P, Seeman E, Liunghall S, et al. (1998). Alendronate in postmenopausal and glucocorticoid-induced osteoporosis. Osteoporosis Int.
115 Dempster DW, Cosman F, Kurland ES, Miller R, Nieves J, Woelfert L, Shane E, Plavetic K, Bilezikian JP, Lindsay R. (2000). Two and three-dimensional structural analysis of paired biopsies from osteoporotic patients before and after treatment with parathyroid hormone. J Bone Miner Res.
116 Devogelaer JP, Broll H, Correa-Rotter R, Cumming DC, De Deuxchaisnes CN, Geusens P, Hosking D, Jaeger P, Kaufman JM, Leite M, Leon J, Liberman U, Menkes CJ, Meunier PJ, Reid I, Rodriguez J, Romanowicz A, Seeman E, Vermeulen A, Hirsch LJ, Lombardi A, Plezia K, Santora AC, Yates AJ, Yuan W. (1996). Oral alendronate induces progressive increases in bone mass of the spine, hip, and total body over 3 years in postmenopausal women with osteoporosis. Bone.
117 Devogelaer JP, Boutsen Y. et al. Comparison of sodium fluoride + calcium with intravenous pamidronate in the therapy of glucocorticoid-induced osteoporosis. 1996. Rec #: 1514
118 Dilsen, G.; Sindel, D., and et al. Effect of nasal calcitonin on pain in osteoporotic patients with vertebral fractures. Rec #: 1683
119 Dimai HP, Sieghart S, Klaushofer K. (1999). Evidence-based medicine in osteoporosis: a review of selcted clinical trials. J Bone Miner Res.
120 Dissemination, Centre for Reviews and. Combining bisphosphonates with hormone therapy for postmenopausal osteoporosis (Provisional record). Database of Abstracts of Reviews of Effectiveness. 2005(3). Rec #: 1226
121 ---. Preventing fractures in postmenopausal women with osteoporosis: a review of recent controlled trials of antiresorptive agents (Structured abstract). Database of Abstracts of Reviews of Effectiveness. 2005(3). Rec #: 1218
122 Djandji M, Sampalis JS, Karaplis AC. (2004). Early effects and safety of alendronate (FOSAMAX) 70 mg once weekly (EASY). J Bone Miner Res.
123 Dore RK, Hodsman AB, Scheele WH, et al. (2001). Changes in bone mineral density 18 months after cessation of Recombinant Human Parthyroid Hormon (1–34) or alendronate treatment in postmenopausal women with osteoporosis. Arthritis Rheum.
124 Dore RK, Krege JH, Chen P, et al. (2004). Back pain risk in postemenopausal women with osteoporosis treated with teriparatide as compared with alendronate: results from two double-blind comparator trials. Osteoporos Int.
125 Downs RW, Bell H, Walsh B, et al. (2000). Two-year results: alendronate vs intranasal calcitonin. J Bone Miner Res.
126 Dufrense TB, Chmeilewski PA, Manhart MD. (2003). Risedronate preserves bone architecture in early postmenopausal women in 1 year as measured by three-dimensionsal microcomputed tomography. Calcif Tissue Int.
127 Dumitrache, C.; Grigorie, D.; Barbu, C., and et al. Osteoporos Int. 2002 Apr; 13(Suppl. 1):S46–7. Rec #: 2141
128 Dunn CJ, Fitton A, Sorkin EM. (1994). Etidronic acid. A review of its pharmacological properties and therapeutic efficacy in resorptive bone disease. Drugs Aging.
129 Durmaz B, Kirazli Y, Erer F. (2000). The effect of calcitriol and alendronate on bone mineral density in postmenopausal women. Ann Rheum Dis.
130 Eastell R, Adams J. (2002). Results of the ‘Arimidex’ (anastrozol,A), tamoxifen (T) or in combination (C) (ATAC) trial: Effects on bone mineral density (BMD) and bone turnover (ATAC Trialists' Group). Annals of Oncology.
131 Eastell, R. ; Devogelaer, J. P.; Peel, N. F. A.; Gill, C.; Bax, D. E.; de Nagant-Deuxchaisnes, C., and Russell, R. G. G. J Bone Miner Res. 1996; 11(1812). Rec #: 3068
132 Eggelmeijer F, Papapoulos SE, van Paassen HC, Dijkmans BA, Valkema R, Westedt ML, Landman JO, Pauwels EK, Breedveld FC. (1996). Increased bone mass with pamidronate treatment in rheumatoid arthritis. Results of a three-year randomized, double-blind trial. Arthritis and Rheumatism.
133 Eid P, Scuderi G, Aroldi A, Ciammella M, Nencioni T. (1996). Bone loss after renal transplantation: HRT versus calcitriol in postmenopausal recipients. Osteoporosis International.
134 Elhusseini A, Elagroudy A, Elsayed M, Sobh M, Ghoneim M. (2003). Treatment of bone loss in renal transplant children and adolescents. Nephrology Dialysis Transplantation.
135 Emkey R, Lane N, Liberman U, et al. (1998). Safety of oral alendronate in patients receiving glucocorticoids. Bone.
136 Emkey R, Reading W, Procaccini R, Gaich GA. (1994). The effect of calcitonin on bone mass in steroid-induced osteoporosis. Arthritis Rheum.
137 Epperly, T. D. and Moore, K. E. Diagnosis, prevention, and treatment of osteoporosis in men. J Gend Specif Med. 2002 Nov–2002 Dec 31; 5(6):33–8. Rec #: 2255
138 Epstein S. (2000). Postmenopausal osteoporosis: fracture consequences and treatment efficacy vary by skeletal site. Aging (Milano).
139 Erdtsieck RJ, Pols HA, Valk NK, van Ouwerkerk BM, Lamberts SW, Mulder P, Birkenhager JC. (1995). Treatment of post-menopausal osteoporosis with a combination of growth hormone and pamidronate: a placebo controlled trial. Clin Endocrinol (Oxf).
140 Erenus M, Gurler A, Binoz S. (2000). Effect of adding alendronate to hormone replacement therapy on bone mineral density in established postmenopausal osteoporosis. Marmara Medical Journal.
141 Eriksson SA, Lindgren JU. (1993). Combined treatment with calcitonin and 1,25-dihydroxyvitamin D3 for osteoporosis in women. Calcif Tissue Int.
142 Erkkola, R. S.; Halonen, K.; Heikkinen, J.; Kivnen, S., and Lammintausta, R. Comparison of FC127a, a novel SERM, and raloxifene in postmenopausal women: a 12-week clincal phase II study [abstrat]. 11th International Congress of Endocrinology; Sydney, Australia. Rec #: 1093
143 Erlacher L, Kettenbach J, Kiener H, Graninger W, Kainberger F, Pietschmann P. (1997). Salmon calcitonin and calcium in the treatment of male osteoporosis: the effect on bone mineral density. Wien Klin Wochenschr.
144 Ettinger, B.; Black, D.; Cummings, S.; Genant, H.; Gluer, C., and Lips, P. et al. The effect of raloxifene in the treatment of osteoporosis: 24-month interim results [abstract]. The North American Menopause Society 9th Annual Meeting.; Toronto. Rec #: 1097
145 Ettinger, B.; Pressman, A.; Schein, J., and et al. Alendronate use among 812 women: Prevalence of gastoinstestinal compaints, noncompliance with patient instructions, and discontinuation. J Managed Care Pharm. 1998 Sep–1998 Oct 31; 4(5):488–92. Rec #: 2120
146 Ettinger B, San Martin J, Crans GG. (2003). Response of markers of bone turnover and bone density to teriparatide in postmenopausal women previously treated with an antiresorptive drug. J Bone Miner Res.
147 ---. Response of markers of bone turnover and bone density to teriparatide in postmenpausal women previously treated with an antiresorptive drug. American Society for Bone and Mineral Research 25th Annual Meeting. Rec #: 3163
148 Ettinger B, San Martin JA, Crans G. (2003). Early response of bone turnover markers and BMD to teriparatide[recombinant human parathyroid hormone (1–34)] in postmenopausal women previously treated wtih an antiresorptive drug. J Bone Miner Res.
149 Early response of bone turnover markers and bone density to teriparatide[recombinant human parathyroid hormone(1–34)] in postmenopausal women previously treated with an anitresorptive drug. J Bone Miner Res. 2002; 17(Suppl 1):S157. Rec #: 3046
150 Ettinger, B.; San Martin, J. A.; Crans, G., and Pavo, I. Response of markers of bone turnover and bone density to teriparatide in postmenopausal women previously treated with an antiresorptive drug. 2003; 18, (suppl 2): S-15. Rec #: 3080
151 Evio S, Tiitinen A, Laitinen K, Ylikorkala O, Valimaki M. (2003). Effects of alendronate and hormone replacement therapy, alone or in combination, on bone mass and markers of bone turnover in elderly women with osteoporosis. International Journal of Obstetrics & Gynecology.
152 Falch JA, Odegaard OR, Finnanger AM, Matheson I. (1987). Postmenopausal osteoporosis: no effect of three years treatment with 1,25-dihydroxycholecalciferol. Acta Med Scand.
153 Fan S, Almond MK, Ball E, Evans K, Cunningham J. (2003). Treatment of bone loss in renal transplant children and adolescents. Nephrology Dialysis Transplantation.
154 Favus M, Emkey R, Leite M, et al. (1997). Five-year treatment of osteoporosis in postmenopausal women with oral alendronate: effects on bone mass and turnover and safety. J Bone Miner Res.
155 Fediani B, Allegri A, Storri L, et al. (2000). Effects of alendronate on heel stiffness and axial BMD in prevention and therapy of glucocorticoid induced osteoporosis. Osteoporos Int.
156 Fentiman, I. S.; Saad, Z.; Caleffi, M.; Chaudary, M. A., and Fogelman, I. Tamoxifen protects against steroidinducedbone loss. European Journal of Cancer (Oxford, England. 1992; 1990) 28(2–3):684–5. Rec #: 1453
157 Fernandez E, La Vecchia C, Franceschi S, Braga C, Talamini R, Negri E, Parazzini F. (1998). Oral contraceptive use and risk of colorectal cancer. Epidemiology.
158 Fioretti P, Gambacciani M, Taponeco F, Melis GB, Capelli N, Spinetti A. (1992). Effects of continuous and cyclic nasal calcitonin administration in ovariectomized women. Maturitas.
159 Fittipaldi MR, Fonderico F, Vitale G, Ciccarelli A, Lupoli GA, Cascella T, Panico A, Lupoli G. (2002). Osteoporosis treatment in elderly hyperthyroid male patients. Journal of Endocrinological Investigation.
160 Flicker, L. ; Larkins, R.; Hopper, J., and Wark, J. Nandralone decanoate and intranasal calcitonin as therapy in established osteoporosis. Rec #: 1801
161 Fogelman I. (2005). Where now for the management of osteoporosis?. Hosp Med.
162 Fraher, L. J. and Hodsman, A. B. Biochemical markers of bone collagen turnover in osteoporotic patients treated with 1–34 parathyroid hormone (teriparatide). 1993. Rec #: 1235
163 Franck H. (1998). The effect of selective oestrogen receptor modulating (SERM) pharmaceuticals in osteoporosis therapy - the result of a 2 year multi-centre study with Raloxifen. Zeitschrift Fur Rheumatologie.
164 Frediani B, Allegri A, Storri L, et al. (2000). Alendronate in the treatment of osteoporosis in men: monitoring by quantitative ultrasound sonography (QUS) and fan-beam x-ray absorpitometry. Osteoporos Int.
165 Frediani, B.; Allegri, A.; Storri, L.; Falsetti, P.; Bisogno, S.; Baldi, F., and Marcolongo, R. Alendronate plus calcitriol: a combined treatment in corticosteroid induced osteoporosis. 1999. Rec #: 1837
166 Freedman L, Anderson G, Kipnis V, Prentice R, Wang CY, Rossouw J, Wittes J, DeMets D. (1996). Approached to monitoring the results of long-term disease prevention trials: examples from the Women's Health Initiative. Control Clin Trials.
167 Fromm GA, Vega E, Plantalech L, Galich AM, Mautalen CA. (1991). Differential action of pamidronate on trabecular and cortical bone in women with involutional osteoporosis. Osteoporos Int.
168 Fu MJ, Huang P, Wang MJ, Shu YM, Wu XD, Xing ZF, Zhou DH. (2002). [ The influence of alendronate on the bone-metery density in the elderly men with osteoporosis]. Practical Geriatrics.
169 Fugere P, Scheele WH, Srikanth KR, Anglin G, Strack TR, Nauden AB, et al. (1999). Raloxifiene does not stimulate the uterus in postmenopausal women as compared to continuos combined hormone replacement therapy following 24 months of treatment [abstract]. Fertil Steril.
170 Fujita T. (2001). Parathyroid hormone in the treatment of osteoporosis. BioDrugs.
171 Fujita T, Orimo H, Inoue T, Kaneda K, Sakurai M, Morita R, Morii H, Yamamoto K, Takaoka K. (1993). Double-blind Multicenter Comparative Study with Alfacalcidol of Etidronate Disodium (EHDP) in Involutional Osteoporosis. Rinsho Hyoka (Clinical Evaluation).
172 Fujiwara S, Kasagi F, Yamada M, Kodama K. (1997). Risk factors for hip fracture in a Japanese cohort. J Bone Miner Res.
173 Gallacher SJ, Boyle IT, Capell HA. (1991). Pseudogout associated with the use of cyclical etidronate therapy. Scott Med J.
174 Garnero P, Valimaki M, Hosking D, et al. (2003). Reduction of type II collagen degradtion in post menopausal women with osteoporosis by alendronate once-weekly and risedronate. J Bone Miner Res.
175 Genant HK, Wu CY, van Kuijk C, Nevitt MC. (1993). Vertebral fracture assessment using a semiquantitative technique. J Bone Miner Res.
176 Gennari C, Gonnelli S, Bruni D, Gennari L, Brandi ML. (2002). PTH in the pathogenesis and treatment of glucocorticoid-induced osteoporosis. Front Horm Res.
177 Gennari C, Gonnelli S, Monaci G, Campagna MS, Franci B. (1993). Evaluation of pharmacodynamic activity of synthetic salmon calcitonin in osteoporotic patients. Comparison between rectal and intramuscular administration. Giornale Italiano Di Ricerche Cliniche e Terapeutiche.
178 Gennari C, Passeri M, Chierichetti SM, Piolini M. (1983). Side-effects of synthetic salmon and human calcitonin. Lancet.
179 Gennari C, Reginster JY. (1998). Bisphosphonates and osteoporosis treatment in Italy. Aging (Milano).
180 Gerber V, Thiebaud D. et al. Dose response with intravenous pamidronate (APD) in postmenopausal osteoporosis: comparison of 60/15, 30 and 60 mg. 1996. Rec #: 1526
181 Gerhard-Herman M, Hamburg N, Ganz P. (2000). Hormone replacement therapy and cardiovascular risk. Curr Cardiol Rep.
182 Gertz BJ, Harris ST, et al. (1993). Effect of short term treatment with alendronate on lumbar bone mineral density in early postmenopausal women. Osteoporos-Int.
183 Gillespie, L. D.; Gillespie, W. J.; Robertson, M. C.; Lamb, S. E.; Cumming, R. G., and Rowe, B. H. Interventions for preventing falls in elderly people. Cochrane Database Syst Rev. 2001; (3):CD000340. Rec #: 3092
184 Giorgino, R. and Mancuso, S. Oral alendronate and calcaneus ultrasound densitometry: a three-year prospective study. 1997. Rec #: 1920
185 Girola M, Ventura P, Birolini F, Germogli R, Molteni R. (1992). Rectal calcitonin administration: Randomized controlled trial versus intranasal route. <ORIGINAL> SOMMINISTRAZIONE DI CALCITONINA IN CAPSULE RETTALI: STUDIO CONTROLLATO RANDOMIZZATO IN CONFRONTO ALLA VIA INTRANASALE. Acta Toxicol Ther.
186 Goemaere S, Correa-Rotter R, Saag K, et al. (1998). Alendronate increases spine BMD irrespective of glucocorticoid dose or duration. Bone.
187 Gonelli S, Rottoli P, Cepollaro C, Pondrelli C, Cappiello V, Vagliasindi M, Gennari C. (1997). Prevention of corticosteroid-induced osteoporosis with alendronate in sarcoid patients. Calcif Tissue Int.
188 Gonnelli, S.; Cepollaro, C., and et al. Growth hormone with and without salmon calcitonin in the treatment of postmenopausal osteoporosis. Rec #: 1702
189 Gonnelli, S.; Palmieri, R., and et al. Rectal salmon calcitonin treatment in post-menopausal osteoporotic patients. A double-blind placebo controlled study. Rec #: 1842
190 Gouva, L. and Tsatsoulis, A. The role of estrogens in cardiovascular disease in the aftermath of clinical trials. Hormones (Athens). 2004 Jul–2004 Sep 30; 3(3):171–83. Rec #: 3444
191 Greenspan, S. and rosen, C. Current and upcoming treatments for fracture prevention. Report of the Surgeon General 's Workshop on Osteoporosis and Bone Health. Washington, D.C.; 2002 Dec 12–2002 Dec 13(; 13–13). Rec #: 2108
192 Greenspan, S. L.; Field-Munves, E. M.; Tonino, R. P., and et al. Alendronate 70 mg once weekly vs. placebo: tolerability study in patietns with osteoporosis [abstract]. 2001; 16, (Suppl 1): S405 Abstract MSU403. Rec #: 2958
193 Grey AB, Stapleton JP, Evans MC, Tatnell MA, Reid IR. (1996). Effect of hormone replacement therapy on bone mineral density in postmenopausal women with mild primary hyperparathyroidism. A randomized, controlled trial. Ann Intern Med.
194 Gruber B, Goenmaere S, Liberman UA, et al. (1998). Alendronate increases bone mineral density in men receiving glucocortcoids. Arthritis Rheum.
195 Guanabens, N.; Farrerons, J., and et al. Comparison of the efficiency and safety of cyclic etidronate versus sodium fluoride in postmenopausal osteoporosis. 1996. Rec #: 1621
196 Guanabens, N.; Pares, A., and et al. Cyclical etidronate versus sodium fluoride for treatment of osteoporosis in primary biliary cirrhosis. Preliminary results after two years. 1996. Rec #: 1623
197 Guesens, P. Risedronate reduces risk of hop fracture in elderly women with osteoporosis. 2000; 66, S67. Rec #: 3149
198 Gulsen Demirel G, Paker N, Yilmaz H. (2000). Long term treatment of postmenopausal osteoporosis with calcitonin, alendronate, or alphacalcidiol. Osteoporos Int.
199 Gunness, M. ; Prestwood, K.; Lu, Y, and Muchmore, D. B. Raisz L. Histomorphometric, bone marker,and bone mineral density response to raloxifene HCI and Premarin in postmenopausal women [abstract]. The Endocrine Society 79th Annual Meetin; Minneapolis. Rec #: 1107
200 Guyatt GH. (1998). Evidence-based management of patients with osteoporosis. J Clin Densitom.
201 Haderslev K, Tjellesen L, Sorensen H, Staun M. (2000). Alendronate increases lumbar spine bone mineral density in patientswith crohns disease. A double blind. Gut.
202 Hall GM, Larbre JP, Spector TD, Perry LA, Da Silva JA. (1996). A randomized trial of testosterone therapy in males with rheumatoid arthritis. British Journal of Rheumatology.
203 Hamdy RC, Moore SW, Whalen KE, Landy C. (1998). Nandrolone decanoate for men with osteoporosis. American Journal of Therapeutics.
204 Hang MW, Xu JG, Tao LF. (2001). [Clinical observation on Etidronate combined with calcium and Alpha D3 in the treatment of primary osteoporosis]. Practical Geriatrics.
205 Hanley DA, Ioannidis G, Adachi JD. (2000). Etidronate therapy in the treatment and prevention of osteoporosis. J Clin Densitom.
206 Hannan, F. M; Kyd, P.; Thomas, E., and et al. Comparison of risedronate and alendronate in an osteoporotic clinic. Calcif Tissue Int. 2004 Jun 5–2004 Jun 9; 74(Suppl 1):S87. Rec #: 2076
207 Harju, E.; Punnonen, R.; Tuimala, R.; Salmi, J., and Paronen, I. Vitamin D and calcitonin treatment in patients with femoral neck fracture: a prospective controlled clinical study. J Int Med Res. 1989 May–1989 Jun 30; 17(3):226–42. Rec #: 1994
208 Harper-Wynne C, Ross G, Sacks N, Salter J, Nasiri N, Iqbal J, A'Hern R, Dowsett M. (2002). Effects of the aromatase inhibitor letrozole on normal breast epithelial cell proliferation and metabolic indices in postmenopausal women: a pilot study for breast cancer prevention. Cancer Epidemiol Biomarkers Prev.
209 Harris, S. T.; Wasnich, R., and Ettinger, M. The effects of risedronate plus estrogen compared with estrogen alone in postmenopausal women. Journal of Bone and Mineral Research. 1999; SA404. Rec #: 3096
210 Hartwell D, Hassager C, Overgaard K, Riis BJ, Podenphant JR, Christiansen C. (1990). Vitamin D metabolism in osteoporotic women during treatment with estrogen, an anabolic steroid, or calcitonin. Acta Endocrinologica.
211 Hawkins F, Epstein S, Hamdy N, et al. (1998). Do disease and concomitant medications influence the effect of alendronate on spine BMD in patients receiving glucocorticoids?. Arthritis Rheum.
212 Hawkins SA, Wiswell RA, Schroeder ET. (2002). The relationship between bone adaptations to resistance exercise and reproductive-hormone levels. Journal of Aging & Physical Activity.
213 Hays J, Hunt JR, Hubbell FA, Anderson GL, Limacher M, Allen C, Rossouw JE. (2003). The Women's Health Initiative recruitment methods and results. Ann Epidemiol.
214 Heinonen A, Sievanen H, Kannus P, Oja P, Vuori I. (1996). Effects of unilateral strength training and detraining on bone mineral mass and estimated mechanical characteristics of the upper limb bones in young women. Journal of Bone and Mineral Research : the Official Journal of the American Society for Bone and Mineral Research.
215 Heinonen A, Wang Q, Nicholson P. (2003). High impact exercise and alendronate have an additive effect on calcaneous ultrasound attenuation in postmenopausal women. J Bone Miner Res.
216 Hemminki, E. Advantages and disadvantages of postmenopausal hormone therapy: a preventive trial [Web Page]. Accessed 1905 Aug 3. Available at: http://www.controlled-trials.com/isrctn/trial/--/0/35338757.html. Rec #: 2929
217 ---. Advantages and disadvantages of postmenopausal hormone therapy: a preventive trial. The Estonian Postmenopausal Hormone Therapy Trial. Ongoing study. Starting date of trial not provided. Rec #: 2928
218 Hendriks JT, Smeenk D. (1979). Investigation of bone and mineral metabolism in hyperthyroidism before and after treatment using calcitonin, 47Ca and balance studies. Acta Endocrinol (Copenh).
219 Herd RJ, Blake GM, Fogelman I. (1996). Total body DXA studies in a double blind placebo controlled trial of cyclical etidronate therapy. Osteoporos-Int.
220 Hernandez CJ, Beaupre GS, Marcus R, Carter DR. (2002). Long-term predictions of the therapeutic equivalence of daily and less than daily alendronate dosing. J Bone Miner Res.
221 Herrington DM, Reboussin DM, Brosnihan KB, Sharp PC, Shumaker SA, Snyder TE, Furberg CD, Kowalchuk GJ, Stuckey TD, Rogers WJ, Givens DH, Waters D. (2000). Effects of estrogen replacement on the progression of coronary-artery atherosclerosis. N Engl J Med.
222 Hesch RD, Heck J, Delling G, Keck E, Reeve J, Canzler H, Schober O, Harms H, Rittinghaus EF. (1988). Results of a stimulatory therapy of low bone metabolism in osteoporosis with (1–38)hPTH and diphosphonate EHDP. Protocol of study I, osteoporosis trial Hannover. Klin Wochenschr.
223 Heshmati HM, Khosla S, Robins SP, O'Fallon WM, Melton LJ, Riggs BL. (2002). Role of low levels of endogenous estrogen in regulation of bone resorption in late postmenopausal women. J Bone Miner Res.
224 Hesp R, Hulme P, Williams D, Reeve J. (1981). The relationship between changes in femoral bone density and calcium balance in patients with involution osteoporosis treeated with human parathyroid hormone fragment hPTH (1–34). Metab Bone Dis Relat Res.
225 Hodgson, S. F.; Watts, N. B.; Bilezikian, J. P.; Clarke, B. L.; Gray, T. K.; Harris, D. W; Johnston, C. C.; Kleerekoper, M.; Lindsay, R.; Luckey, M. M.; McClung, M. R.; Nankin, H. R.; Petak, S. M., and Recker, R. R. American Association of Clinical Endocrinologists 2001 Medical Guidelines for Clinical Practice for the Prevention and Management of Postmenopausal Osteoporosis. Endocr Pract. 2001 Jul–2001 Aug 31; 7(4):293–312. Rec #: 2973
226 Hodsman, A. B. and Lindsay, R. Effects of 1–84 PTH over 1 year. j Clin Endocrinol Metab. 2003. Rec #: 3044
227 Honeywell M, Phillips S, Branch E. (2003). Teriparatide fro osteoporosis: a clinical review. Pharmacy and Therapeutics.
228 Hooper, M.; Ebeling, P.; Roberts, A.; D'Emden ; Nicholson, G.; Crusan, C.; Wenderoth, D., and Ethgen, D. Risedronate prevents bone loss in early postmenopausal women. S69. Rec #: 3005
229 Hooper, M.; Ebeling, P.; Roerts, A.; D'Emden, M.; Nicholson, G.; Crusan, C.; Wenderoth, D., and Ethgen, D. Risedronate prevents bone loss in early postmenopausal women. 1999; 64, (Suppl 1): S69. Rec #: 3128
230 Hosking DJ, McClung MR, Ravn P, et al. (1996). Alendronate in the prevention of osteoporosis: epic study two-year results. J Bone Miner Res.
231 Houtkooper LB, Ritenbaugh C, Aickin M, Lohman TG, Going SB, Weber JL, Greaves KA, Boyden TW, Pamenter RW, Hall MC. (1995). Nutrients, body composition and exercise are related to change in bone mineral density in premenopausal women. The Journal of Nutrition.
232 Howell A. (2003). An assessment of fracture rates over time (between 6 and 48 months) in the ATAC (Arimidex, Tamoxifen, Alone or in Combination) trial. European Journal of Cancer.
233 Isaia G, Campagnoli C, Mussetta M, Massobrio M, Salamano G, Gallo M, Molinatti GM. (1989). Calcitonin and lumbar bone mineral content during oestrogen-progestogen administration in post-menopausal women. Maturitas.
234 Isaia GC, Di SM, Sciolla A, Mussetta M, Vassellatti D. (1995). Salmon synthetic calcitonin suppositories in the short-term treatment of involutive osteoporosis. Minerva Medica.
235 Isaia GC, Di Stefano M, Sciolla A, Mussetta M, Vassellatti D. (1995). [Synthetic salmon calcitonin suppositories for the short-term treatment of involutive osteoporosis]. Minerva Medica.
236 Isaia, G. C.; Mussetta, M., and et al. Effects of salmon calcitonin suppositories in patients with postmenopausal and senile osteoporosis. Rec #: 1824
237 Ishida, Y. and Kawai, S. Comparative efficacy of hormone replacement therapy, bisphosphonates, calcitonin, vitaminD and vitamin K in postmenopausal women with osteoporosis. 25th Annual Meeting of the American Society for Bone and Mineral Research; Minneapolis, MN. Rec #: 2105
238 Ishizaka K, Suzuki M, Kageyama Y, Kihara K, Yoshida K. (2002). Bone mineral density in hypogonadal men remains low after long-term testosterone replacement. Asian J Androl.
239 J, Adachi. Etidronate in corticosteroid-induced osteoporosis. 1999. Rec #: 1458
240 Jacobs EJ, White E, Weiss NS, Heckbert SR, LaCroix A, Barlow WE. (1999). Hormone replacement therapy and colon cancer among members of a health maintenance organization. Epidemiology.
241 Jamal, S. A. Combination therapies for osteoporosis. J Am Pharm Assoc (Wash DC). 2004 Mar–2004 Apr 30; 44(2):119; author reply 119. Rec #: 2199
242 Jeffery JR, Leslie WD, Karpinski ME, Nickerson PW, Rush DN. (2003). A randomized prospective trial of calcitriol versus alendronate for the treatment of osteopenia in renal transplant recipients. American Journal of Transplantation.
243 Jencen, D.; Reid, D.; Devogelaer, J. P., and et al. Risedronate is safe and well tolerated in treating corticosteroid-induced osteoporosis. 2nd Meeting of the ASBMR-IBMS; San Francisco, CA. Marathon Multimedia. Rec #: 3213
244 Jenkins EA, Walker-Bone KE, Wood A, McCrae FC, Cooper C, Cawley MID. (1997). The prevention of corticosteroid induced osteoporosis with intermittent cyclical etidronate. Bone.
245 Jiang Y, Zhao JJ, Mitlak BH, Wang O, Genant HK, Eriksen EF. (2003). Recombinant human parathyroid hormone (1–34) teriparatide improves both cortical and cancellous bone structure. Journal of Bone and Mineral Research : the Official Journal of the American Society for Bone and Mineral Research.
246 Johnell, O.; Scheele, W.; Lu, Y., and Lakabrianan, M. Effects of raloxifene (RLX), alendronate (ALN) and RLX + ALN on bone mineral density (BMD) and biochemical markers bone turnover in postmenopausal women with osteoporosis. 1999; 14, S157 (abstract). Rec #: 2996
247 Johnson RE, Specht EE. (1981). The risk of hip fracture in postmenopausal females with or without estrogen drug exposure. Am J Public Health.
248 Johnston, C. C. A selective estrogen receptor modulator for the treatment of osteoporosis. 1997. Rec #: 1169
249 Kamel HK. (2003). Hip fracture prevention in the nursing home. Annals of Long-Term Care.
250 Kanis JA, Brazier JE, Stevenson M, Calvert NW, Lloyd Jones M. (2002). Treatment of established osteoporosis: a systematic review and cost-utility analysis. Health Technol Assess.
251 Kapuscinski, P.; Talalaj, M.; Borowicz, J.; Marcinowska-Suchowierska, E., and Brzozowski, R. An analgesic effect of synthetic human calcitonin in patients with primary osteoporosis. Rec #: 1671
252 Kelly R, Taggart H. (1997). Incidence of gastrointestinal side effects due to alendronate is high in clinical practice. BMJ.
253 Kemper, H. C. G.; Bakker, I.; van Tulder, M. W.; Kostense, P. J., and Courteix, D. Exercise for preventing low bone mass in young males and females. Cochrane Database of Systematic Reviews. 2005(3). Rec #: 1268
254 Kessenich CR. (2000). Risedronate: a new bisphosphonate for the treatment of osteoporosis. Nurse Pract.
255 Khan, M. A.; Hlatky, M. A.; Liu, M. W.; Lin, F.; Rogers, W. J., and Shlipak, M. G. Effect of postmenopausal hormone therapy on coronary heart disease events after percutaneous transluminal coronary angioplasty. Am J Cardiol. 2003 Apr 15; 91(8):989–91, A7. Rec #: 3199
256 Kirizal Y, Durmaz B, Erer F, et al. (2000). Comparison of the efficacy of alendronate in elderly with the efficacy in early postmenopausal women. Osteoporosis Int.
257 Kleinstueck DB, Santiestiban H, Benet LZ, Frassetto LA. (2001). Effects of short-term alendronate on bone mineral density in end stage renal disease. Journal of the American Society of Nephrology.
258 Koc, M.; Tuglular, S.; Arikan, H.; Ozener, C., and Akoglu, E. Alendronate increases bone mineral density in renal transplant recipients. 2001. Rec #: 1721
259 Korsic M. (2003). [The role of raloxifene (Evista) in the treatment and prevention of postmenopausal osteoporosis]. Reumatizam.
260 Kraenzlin ME, Seibel MJ, Trechsel U, Boerlin V, Azria M, Kraenzlin CA, Haas HG. (1996). The effect of intranasal salmon calcitonin on postmenopausal bone turnover as assessed by biochemical markers: evidence of maximal effect after 8 weeks of continuous treatment. Calcif Tissue Int.
261 Kraj M, Poglod R, Maj S, Pawlikowski J, Sokolowska U, Szczepanik J. (2002). Comparative evaluation of safety and efficacy of pamidronate and zoledronic acid in multiple myeloma patients (single center experience). Acta Poloniae Pharmaceutica.
262 Krege, J. H. Increase in serum-terminal propeptide of type I collagen with teriparatide treatment predict increases in lumbar spine bone density. The Endocrine Society's 85th Annual Meeting. Rec #: 3170
263 Krieg, M. A.; Thiebaud, D.; Gillard-beruer, D.; Goy, J. J., and Burckhardt, P. Intermittent intervenous pamidronate prevents the dramatic bone loss after heart transplantation. J Bone Miner Res. 1996; 11(S345). Rec #: 3076
264 Krueger, D.; Checovich, M.; Gemar, D.; Wei, X., and Binkley, N. Calcium supplement ingestion may alter lumbar spine bone mineral density measurement. J Clin Densitom. 2006 Apr–2006 Jun 30; 9(2):159–63. Rec #: 3554
265 Kucuk S, Gokdeniz R, Atmaca R, Uryan I, Buhur A, Taskin O. (1999). Effect of etidronate on urinary Calcium/Creatinin ratio in postmenopausal women: A prospective, randomized, placebo controlled study. Turkish Journal of Medical Sciences.
266 Kulkarni PM, Gaich GA, Scheele WH. (2001). Lumbar spine bone mineral density response rates in a study of Recombinant Huamn Parathyroid Hormone (1–34) compared to alendronate sodium in postmenopausal women with osteoporosis. Arthritis Rheum.
267 Kuntz D, Marie P, Berhel M, Caulin F. (1986). Treatment of post-menopausal osteoporosis with phosphate and intermittent calcitonin. International Journal of Clinical Pharmacology Research.
268 Lan, N. F.; Thompson, J. M., and Strewler, G. J. Intermittent treatment with human parathyroid hormone [hPTH (1–34)] inceased trabecular bone volume but not connectivity in osteopenic rats. 1995 Oct; 1470–7. Rec #: 3147
269 Landsay R, Scheele WH, Clancy AD, Mitlak BH. (2001). Incident vertebral fractures during an 18-month observation period following discontinuation of LY333334 [recombinanat human parathyroid hormone (1–34), rhPTH (1–34)] use in postmenopausal women with osteoporosis. J Bone Miner Res.
270 Lees B, Garland SW, et al. (1996). Changes in bone density in healthy postmenopausal women with oral pamidronate. Osteoporos-Int.
271 Lems W, Lodder M, lips P, et al. (2003). Effect of alendronate in patients with rheumatoid arthritis on chronic treatment with low dose prednisone. J Bone Miner Res.
272 Levy C, Harnois DM, Angulo P, Jorgensen R, Lindor KD. (2005). Raloxifene improves bone mass in osteopenic women with primary biliary cirrhosis: results of a pilot study. Liver Int.
273 Licata AA. (1990). Diphosphonates in the treatment of osteoporosis. Cleve Clin J Med.
274 Licata AA; Chesnut CC III; Genant HK, and Et al. Effects of 2 years' follow-up cyclical etidronate treatment in postmenopausal osteoporotic women. 1993; 8, (Supp 1): S141. Rec #: 2878
275 Lindsay, R. ; Burge, R. T., and Strauss, D. M. The expected cost of new fractures in the year following a vertebral fracture. 2001; 16, (suppl 1): S275. Rec #: 3131
276 Lindsay R, Cosman F. (1990). Estrogen in prevention and treatment of osteoporosis. Ann N Y Acad Sci.
277 Lindsay, R. ; Hodsman, A. B.; Genant, H.; Bolognese, M., and Ettinger, M.1998: S175. Rec #: 3157
278 Lindsay, R. ; Kendler, D., and McClung, M. Risedronate 35mg once a week is as effective as 5 mg daily in postmenopausal women. 2001; 44, (9 suppl): 604. Rec #: 3146
279 Lindsay, R. ; Ste-Marie, L. G., and Scheele, W. H. Bone mineral density changes during an 18 month observational period following discontinuation of recombinant human parathyroid humone (1–34) treatment of postmenopausal women receiving hormone replacement therapy. JAMA. 2004. Rec #: 3049
280 Lips P, Graafmans WC, Ooms ME, Bezemer PD, and Bouter LM. (1996). Vitamin D supplementation and fracture incidence in elderly persons. A randomized, placebo-controlled clinical trial. Ann Intern Med.
281 Ljunghall S, Gardsell P, Johnell O, Larsson K, Lindh E, Obrant K, Sernbo I. (1991). Synthetic human calcitonin in postmenopausal osteoporosis: a placebo-controlled, double-blind study. Calcif Tissue Int.
282 Lobianco R, Merola B, Lupoli G, Cocca A, Guarino M, Pia M, Guerriero S, Lombardi G. (1992). [Randomized comparative study using carbocalcitonin i.m. vs carbocalcitonin nasal spray vs ipriflavone × os in the treatment of post-menopausal osteoporosis]. Minerva Endocrinologica.
283 Lorenzin MG, Bianco V, Pasini T, Franzosi N. (1993). Prevention of postmenopausal osteoporosis: A comparison of four treatment schedule. <ORIGINAL> VALUTAZIONE COMPARATIVA AD UN ANNO DI QUATTRO SCHEMI DI TERAPIA PREVENTIVA DELLA OSTEOPOROSI POSTMENOPAUSALE. Annali Di Ostetricia Ginecologia Medicina Perinatale.
284 Love RR. (1990). Bone Density and Cardiovascular Risk Factor Changes in Postmenopausal Women Treated with Tamoxifen. British Journal of Cancer.
285 Love RR, Mazess RB, Tormey DC, Barden HS, Newcomb PA, Jordan VC. (1988). Bone mineral density in women with breast cancer treated with adjuvant tamoxifen for at least two years. Breast Cancer Res Treat.
286 Love RR, Mazess RB, Epstein S, Wiebe DA, Demets DL. (1990). Bone mineral density (BMD) preservation with tamoxifen treatment in postmenopausal women: results of a placebo-controlled trial. Breast Cancer Research & Treatment.
287 Love RR, Mazess RB, Tormey DC, Rasmussen P, Jordan VC. (1987). Bone mineral density (BMD) in women with breast cancer treated with tamoxifen for two years. Breast Cancer Research & Treatment.
288 Lozano-Tonkin, C.; Gonzalez, M. A., and et al. Long-term treatment of postmenopausal osteoporosis with sodium etidronate or calcitonin. 1996. Rec #: 1645
289 Lozano-Tonkin C, Gracia A. Jareno J. Mercadal J. [Double-blind study on the efficacy of long-term intermittent nasal elcatonin in recent postmenopausal women]. Anales De Medicina Interna (Madrid, Spain. 2000; 1984) 17(8):399–405. Rec #: 1474
290 Lozano-Tonkin C, Gracia Canales A, Jaren o J, Mercadal J. (2000). Long-term double-blind study of the efficacy of intermitent nasal elcatonin in recent postmenopausal women. Anales De Medicina Interna.
291 Luengo M, Picado C. (1992). Calcitonin nasal spray treatment of steroid-induced osteopenia in chronic steroid dependent asthma: a one year follow-up study. European Respiratory Journal.
292 Luengo M, Picado C, Del Rio L, Guanabens N, Montserrat JM, Setoain J. (1990). Treatment of steroid-induced osteopenia with calcitonin in corticosteroid-dependent asthma. A one-year follow-up study. Am Rev Respir Dis.
293 Luengo, M.; Picado, C.; del Rio, L.; Guanabens, N.; Setoain, J., and Agusti-Vidal, A. Evaluation of calcitonin treatment in steroid osteoporosis in chronic corticodependent asthma. Preliminary results at 6 months therapy. Rec #: 1954
294 Luengo, M. and Picardo, C. Calcitonin “nasal spray” treatment of steroid-induced osteopenia in chronic steroid-dependent asthma. A two year follow-up study. Rec #: 1814
295 Lufkin, E.; Whitaker, M., and et al. Raloxifene promising treatment in osteoporosis. 1997. Rec #: 1714
296 Luisetto G, Bottega F, Zangari M, Tizian L, Scalella P, Pozzuoli A. (1996). Effects of three therapeutic regimens on postmenopausal bone loss in oophorectomized women. Current Therapeutic Research Clinical and Experimental.
297 Lyngsoe J, Sorensen M, Sjostrand H, Sengelov H, Thrane MT, Holst J. (1992). The effect of sustained release verapamil on glucose metabolism in patients with non-insulin-dependent diabetes mellitus. Drugs.
298 Lyritis GP, Magiasis B, Tsakalakos N. (1995). Prevention of bone loss in early nonsurgical and nonosteoporotic high turnover patients with salmon calcitonin: the role of biochemical bone markers in monitoring high turnover patients under calcitonin treatment. Calcified Tissue International.
299 Lyritis GP, Tsakalakos N, Magiasis B, Karachalios T, Yiatzides A, Tsekoura M. (1991). Analgesic effect of salmon calcitonin in osteoporotic vertebral fractures: a double-blind placebo-controlled clinical study. Calcified Tissue International.
300 MacIntyre I, Stevenson JC, Whitehead MI, Wimalawansa SJ, Banks LM, Healy MJ. (1988). Calcitonin for prevention of postmenopausal bone loss. Lancet.
301 MacLean, D. B.; Thompson, D. D., and et al. Droloxifene, the tissue selective estrogen agonist, prevents bone loss in early postmenopausal women without stimulating the uterine endometrium. 1997. Rec #: 1131
302 Maini M, Bozzi M, Brignoli E, Felicetti G. (1995). [Medium- and long-term effects of various treatment schedules with nasal S-calcitonin spray]. Minerva Medica.
303 Malavolta N, Zanardi M, Veronesi M, Ripamonti C, Gnudi S. (1999). Calcitriol and alendronate combination treatment in menopausal women with low bone mass. International Journal of Tissue Reactions.
304 Mallette LE, LeBlanc AD, Pool JL, Mechanick JI. (1989). Cyclic therapy of osteoporosis with neutral phosphate and brief, high-dose pulses of etidronate. J Bone Miner Res.
305 Malnick SD, Gottesfeld F, Walpart A, Keter D, Lurie Y, Beergabel M. (2002). Nonhealing gastric ulcer caused by chronic alendronate administration. MedGenMed.
306 Mao LF, Hu ZH. (2001). Alendronate and calcium carbonate in treatment of postmenopausal osteoporosis. Modern Rehabilitation.
307 Marcus R. (1995). The PEPI trial investigators: effects of hormone replacement therapies on BMD: resulsts from the Postmenopausal Estrogen and Progestin Intervention trial. J Bone Miner Res.
308 Marcus R, Greendale G, Blunt BA, Bush TL, Sherman S, Sherwin R, Wahner H, Wells B. (1994). Correlates of bone mineral density in the postmenopausal estrogen/progestin interventions trial. J Bone Miner Res.
309 Marcus R, Wong M, Heath H, Stock JL. (2002). Antiresorptive treatment of postmenopausal osteoporosis: comparison of study designs and outcomes in large clinical trials with fracture as an endpoint. Endocr Rev.
310 Mascarenhas MR, Almeida F, Galvao-Teles A. (2003). Effects of alendronate sodium therapy in osteporotic males during 48 months on the trabecular and cortical bone. Osteoporos Int.
311 Masiukiewicz US, Insogna KL. (1998). The role of parathyroid hormone in the pathogenesis, prevention and treatment of postmenopausal osteoporosis. Aging (Milano).
312 Matuszkiewicz-Rowinska J, Niemczyk S, Przedlacki J, Puka J, Switalski M, Ostrowski K. (2004). Effect of salmon calcitonin on bone mineral density and calcium-phosphate metabolism in chronic hemodialysis patients with secondary hyperparathyroidism. Polskie Archiwum Medycyny Wewnetrznej.
313 Matzkin H, Chen J, Weisman Y, Goldray D, Pappas F, Jaccard N, Braf Z. (1992). Prolonged treatment with finasteride (a 5 alpha-reductase inhibitor) does not affect bone density and metabolism. Clinical Endocrinology.
314 Maugeri, D. ; Panebianco, P.; Russo, M. S.; Motta, M., and Motta, L. Ipriflavone - New confirmations of efficacy on involutional osteoporosis treatment. <ORIGINAL> IPRIFLAVONE - RECENTI CONFERME DI EFFICACIA NEL TRATTAMENTO DELL'OSTEOPOROSI INVOLUTIVA. G. 1993; GERONTOL. 41(9):359–365. Rec #: 1983
315 Maxim P, Ettinger B, Spitalny GM. (1995). Fracture protection provided by long-term estrogen treatment. Osteoporos Int.
316 Mazzantini M, Nasti P, Mandolesi MC, Di Munno O. (1994). [Short-term effects of salmon calcitonin rectal administration in women with involutive osteoporosis]. Minerva Endocrinologica.
317 Mazzantini, M.; Occhipinti, G., and et al. Treatment of postmenopausal and senile osteoporosis with salmon calcitonin suppositories. Rec #: 1848
318 Mazzuoli, F. Calcitonin treatment in established osteoporosis. Rec #: 1932
319 Mazzuoli GF, Passeri M, Gennari C, Minisola S, Antonelli R, Valtorta C, Palummeri E, Cervellin GF, Gonnelli S, Francini G. (1986). Effects of salmon calcitonin in postmenopausal osteoporosis: a controlled double-blind clinical study. Calcif Tissue Int.
320 Mazzuoli GF, Tabolli S, Bigi F, Valtorta C, Minisola S, Diacinti D, Scarnecchia L, Bianchi G, Piolini M, Dell'Acqua S. (1990). Effects of salmon calcitonin on the bone loss induced by ovariectomy. Calcif Tissue Int.
321 McClung M, Bensen W, Bolognese M, Bonnick S, Ettinger M, Harris S, Knecht T, Lang R, Miller P, Pavlov E, Silverman S, Woodson G, Faulkner K, Ethgen D, Axelrod D. (1998). Risedronate increases bone mineral density at the hip, spine and radius in postmenopausal women with low bone mass. Osteoporosis International.
322 McClung M, Bensen W, Bolognese M, Bonnick S, Ettinger M, Harris S, Knecht T, Lang R, Miller P, Pavlov E, Silverman S, Woodson G, Faulkner K, Ethgen D, Axelrod D. (1998). Risidronate increases bone mineral density at the hip, spine and radius in the ostmenopausal women with low bone mass. Osteoporosis Internationl.
323 McClung M, Clemmesen B, Daifotis A, Gilchrist NL, Eisman J, Weinstein RS, Fuleihan Gel-H, Reda C, Yates AJ, Ravn P. (1998). Alendronate prevents postmenopausal bone loss in women without osteoporosis. A double-blind, randomized, controlled trial. Alendronate Osteoporosis Prevention Study Group. Ann Intern Med.
324 McClung M, Miller P, Civitelli R, et al. (2003). Differential effects of teriparatide and alendronate on markers of boner emodeling and areal and volumetric bone density in women with osteoporosis. J Bone Miner REs.
325 McClung M, Wasnich R, Hosking D, et al. (1993). Safety of oral alendronate on vertabral density and biochemical markers of bone remodeling in early postmenopausal women. J Clin Endocrinol Metab.
326 McClung M, Wasnich R, Omizo M, et al. (2002). Resolution of effect following alendronate: six-year results from the Early Postmenopausal Interventional Cohort (EPIC) study. J Bone Miner Res.
327 McClung M, Yanover M, Menkes CJ, et al. (1998). Alendronate increases bone mass in patients receiving glucocorticoid therapy for pulmonary diseases. J Allergy Clin Immunol.
328 McClung M, E. R. Bensen W. Risedronate reduces hip fracture risk in elderly women with osteoporosis [abstract]. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA. 2000; 11(Suppl 2). Rec #: 3368
329 McClung MR, Miller PD, Civitelli R, et al. (2003). Distinctive effects of teriparatide and alendronate on lumbar spine bone density and bone turnover in women iwth osteoporosis. Osteoprosis Int.
330 McDermott MT, Kidd GS. (1987). The role of calcitonin in the development and treatment of osteoporosis. Endocr Rev.
331 McIntyre JA, Castaner RM, Bayes M. (2005). ED-71: Treatment of osteoporosis vitamin D analogue. Drugs of the Future.
332 Meller I. (1986). Effects of salmon calcitonin in postmenopausal osteoporosis: a controlled double-blind study. Calcif Tissue Int.
333 Melton LJ. (1995). How many women have osteoporosis now?. J Bone Miner Res.
334 Melton LJ, Atkinson EJ, O'Fallon WM, Wahner HW, Riggs BL. (1993). Long-term fracture prediction by bone mineral assessed at different skeletal sites. J Bone Miner Res.
335 Melton LJ, Cummings SR. (1987). Heterogeneity of age-related fractures: implications for epidemiology. Bone Miner.
336 Melton LJ, Lane AW, Cooper C, Eastell R, O'Fallon WM, Riggs BL. (1993). Prevalence and incidence of vertebral deformities. Osteoporos Int.
337 Meschia M, Brincat M, Barbacini P, Maini MC, Marri R, Crosignani PG. (1992). Effect of hormone replacement therapy and calcitonin on bone mass in postmenopausal women. Eur J Obstet Gynecol Reprod Biol.
338 Meunier PJ. (1992). [Intra-nasal calcitonin for the prevention of postmenopausal osteoporosis]. Revista De Medicina De La Universidad De Navarra.
339 Meunier, P. J.; Arlot, M.; Chavassieux, P., and Yates, A. J. The effects of alendronate on bone turnover and bone quality. 1999. Rec #: 1858
340 Meunier, P. J.; Slosman, D., and et al. The strontium salt S-12911: a new candidate for the treatment of osteoporosis [abstract]. Osteoporos-Int. Vol.6 Suppl 1, Pp.241, 1996. 1996. Rec #: 2030
341 Meythaler JM, Korkor AB, Nanda T, Kumar NA, Fallon M. (1986). Immobilization hypercalcemia associated with Landry-Guillain-Barre syndrome. Successful therapy with combined calcitonin and etidronate. Arch Intern Med.
342 Mikula J, Sturc Z, Dolecek R, Skwarlo B, Machalek J. (1989). Double blind experiment with the administration of calcitonine. Rehabilitacia.
343 Milhaud G, Talbot JN, Coutris G. (1975). Calcitonin treatment of post-menopausal osteoporosis. Evaluation of efficacy by principal components analysis. Biomedicine.
344 Miller BE, De Souza MJ, Slade K, Luciano AA. (2000). Sublingual administration of micronized estradiol and progesterone, with and without micronized testosterone: effect on biochemical markers of bone metabolism and bone mineral density. Menopause (New York, NY).
345 Miller P. (2003). Analysis of 1-year vertebral fracture risk reduction data in treatments for osteoporosis. South Med J.
346 Miller, P.; Orwoll, E.; MacIntyre, B.; Smith, M.; Vandormeal, K., and Leung, A. Treatment with alendronate 70 mg once weekly for 12 months increases BMD and decreases biochemical markers of bone turnover in men with osteoporosis. Second International Conference on Osteoporosis in Men; Genoa, Italy. Rec #: 3088
347 Miller P, Schnitzer T, Emkey R, Orwoll E, Rosen C, Ettinger M, Vandormael K, Daifotis A. (2004). Weekly oral alendronic acid in male osteoporosis. Clin Drug Invest.
348 Miller PD. (2004). Combination therapy for osteoporosis: Parathyroid hormone and bisphosphonates. Current Opinion in Orthopaedics.
349 Miller PD, Neal BJ, McIntyre DO, Yanover MJ, Anger MS, Kowalski L. (1991). Effect of cyclical therapy with phosphorus and etidronate on axial bone mineral density in postmenopausal osteoporotic women. Osteoporos Int.
350 Miller PD; Jackson RD; Ross pD, and et al. ICT etidronate for osteoporosis: 5-year results. 1994; 25, (Supp 1): S74. Rec #: 2879
351 Minne HW, Pollhane W, Karpf DB. (1999). The effects of alendronate on stature and the spine deformity index. Int J Clin Pract Suppl.
352 Miyakoshi N. (2004). Effects of parathyroid hormone on cancellous bone mass and structure in osteoporosis. Curr Pharm Des.
353 Mizunuma H, Soda M, Okano H, Kagami I, Miyamoto S, Ohsawa M, Ibuki Y. (1998). Changes in bone mineral density after orchidectomy and hormone replacement therapy in individuals with androgen insensitivity syndrome. Hum Reprod.
354 Montemurro L, Schiraldi G, Fraioli P, Tosi G, Riboldi A, Rizzato G. (1991). Prevention of corticosteroid-induced osteoporosis with salmon calcitonin in sarcoid patients. Calcif Tissue Int.
355 Morgante G, Farina M, Cianci A, La Marca A, Petraglia F, De Leo V. (2004). Veralipride administered in combination with raloxifene decreases hot flushes and improves bone density in early postmenopausal women. Gynecological Endocrinology : the Official Journal of the International Society of Gynecological Endocrinology.
356 Morii, H.; Fuhita, T., and Ishii, J. Raloxifene for treatment of osteoporosis: determination of an adequate dose in Japanese women. 1998; 23, S610 (Abstract). Rec #: 2994
357 Morley P, Whitfield JF, Willick GE. (2001). Parathyroid hormone: an anabolic treatment for osteoporosis. Curr Pharm Des.
358 Mosekilde L, Sogaard CH, Danielsen CC, Torring O. (1991). The anabolic effects of human parathyroid hormone (hPTH) on rat vertebral body mass are also reflected in the quality of bone, assessed by biomechanical testing: a comparison study between hPTH-(1–34) and hPTH-(1–84). Endocrinology.
359 Mucci M, Carraro C, Mancino P, Monti M, Papadia LS, Volpini G, Benvenuti C. (2006). Soy isoflavones, lactobacilli, Magnolia bark extract, vitamin D3 and calcium. Controlled clinical study in menopause. Minerva Ginecol.
360 Muenier PJ, Arlot ME, McClung M, et al. (2004). Contrasting effects of teriparatide and alendronate on bone turnover assessed by bone histomorphometric parameters in women with osteoporosis. Osteoporosis Int.
361 Mugglestone CJ. (1985). Etidronate and risk of fractures. Lancet.
362 Munoz LJ. (1994). Diphosphonates: an efficacious alternative in osteoporosis treatment. Results from a clinical trial with etidronate in primary care. Centro De Salud.
363 Nabhan, F. A.; Islam, A.; Pitale, S., and et al. Does addition of an antiresponsive agent to testerone influence the treatment of osteoporosis in hypogonadal men? Endocrine Society's 85th Annual Meeting.; Philadelphia, PA. v. P2–514). Rec #: 2129
364 Nagant de Deuxchaisnes C, Dufour JP, Devogelaer JP, Huaux JP, Esselinckx W. (1985). Etidronate and the risk of fractures. Lancet.
365 Nakashima M, Kanamaru M, Takenaga N. (1995). Phase I study of alendronate, a new aminobisphosphonate. Japanese Journal of Clinical Pharmacology and Therapeutics.
366 Nannarini M, Fincato G, Galimberti S, Maderna M, Greco F, Castiglioni C. (1994). Analgesic effect of salmon calcitonin suppositories in patients with bone pain. Curr Ther Res Clin Exp.
367 Nassef AMEl-Adawy ; Mostafa, M. I.; Gohar, O. A., and Ebead, W. A. Comparative study of 3 alendronate regimens in treating postmenopausal osteoporosis. 2002. Rec #: 1644
368 Neal AJ, Evans K, Hoskin PJ. (1993). Does long-term administration of tamoxifen affect bone mineral density?. Eur J Cancer.
369 Neer, M.; Slovik, D. M.; Daly, M.; Potts, T., and Nussbaum, S. R. Treatment of postmenopausal osteoporosis with daily parathyroid hormone plus calcitriol. 1993. Rec #: 1986
370 Neer R, Hayes A, Wyland J, et al. (2004). Effects of parathyroid hormone, alendronate, or both on bone density in osteoporotic postmenopausal women. J Bone Miner Res.
371 Neer, R.; Slovik, D.; Daly, M.; Lo, C.; Potts, J., and Nussbaum, S. Treatment of postmenopausal osteoporosis with daily parathyoid hormone plus calcitriol. Proceedings of the Third International Symposium on Osteoporosis. Osteopress ApS; 1990; pp. 1314–7. Rec #: 3112
372 Neer, R. M. ; Arnaud, C.; Zanchetta, J. R.; Prince, R.; Gaich, G. A.; Reginster, J. Y.; Hodman, A. B.; Eriksen, E. F.; Mellstrom, C.; Ish-Shalom, S.; Oefjord, E. S.; Marcinowska-Suchowierska, E.; Salmi, J.; Gaspar, L.; Mulder, H.; Halse, J.; Sawicki, A. Z.; Genant, H.; Want, O., and Mitlak, B. H. Recombinant human PTH[rhPTH(1–34)] reduces the risk of spine and non-spine fractures in postmenopausal osteoporosis. The Endocrine Society 82nd Annual Meeting 2000. Rec #: 3142
373 Neer, R. M. ; Slovik, D., and Doppelt, S. The use of parathyroid hormone plus 1,25 dihydroxyvitamin D to increase trabecular bone in oseoporotic men and postmenopausal women. Osteopress; 1987; pp. 829–835. Rec #: 3110
374 Nelson, M. E. Global recommendations: physical activity in middle-aged and older adults (50 + years of age). In: report of the surgeon General's workshop on osteoporosis and bone health. Washington D.C.; 2002 Dec 12–2002 Dec 13. Rec #: 1084
375 Ner R, Hayes A, Rao A, et al. (2002). Effects of parathyroid hormone, alendronate, or both on bone density in osteoporotic postmenpausal. J Bone Miner Res.
376 Nordal, K. P.; Halse, J., and Dahl, E. The effect of nasal calcitonin on bone mineral density in renal transplant recipients. 1996. Rec #: 1905
377 O'Neill TW, Felsenberg D, Varlow J, Cooper C, Kanis JA, Silman AJ. (1996). The prevalence of vertebral deformity in european men and women: the European Vertebral Osteoporosis Study. J Bone Miner Res.
378 Obel EB, Munk-Jensen N, Svenstrup B, Bennett P, Micic S, Henrik-Nielsen R, Nielsen SP, Gydesen H, Jensen BM. (1993). A two-year double-blind controlled study of the clinical effect of combined and sequential postmenopausal replacement therapy and steroid metabolism during treatment. Maturitas.
379 Odvina CV, Zerwekh JE, Rao DS, Maalouf N, Gottschalk FA, Pak CY. (2005). Severely suppressed bone turnover: a potential complication of alendronate therapy. J Clin Endocrinol Metab.
380 Oleksik A, Lips P, Dawson A, Minshall ME, Shen W, Cooper C, Kanis J. (2000). Health-related quality of life in postmenopausal women with low BMD with or without prevalent vertebral fractures. J Bone Miner Res.
381 Olszynski WP, Adachi JD Chines AA. Intermittent cyclical therapy with etidronate in the prevention of corticosteroid-induced osteoporosis. 1997. Rec #: 1586
382 Ones K, Tetik S, Eryavuz M, et al. (2001). Effects of combined treatment alendronate + alfacalcidol on bone mineral density in postmenopausal osteoporisis. Ann Rheum Dis.
383 Orimo H, Fujita T, Onomura T, Inoue T, Kushida K, Shiraki M. (1992). Clinical Evaluation of Ea-0167 (Menatetrenone) in the Treatment of Osteoporosis. Phase III Double-blind Multicenter Comparative Study with Alfacalcidol. Rinsho Hyoka (Clinical Evaluation).
384 Orimo H, Fujita T, Yoshikawa S, Inoue T, Morita R. (1994). Clinical Study of SMC 20–051 Nasal Spray in Pain due to Osteoporosis. Phase II Dose-finding study. Rinsho Hyoka (Clinical Evaluation).
385 Orimo H, Shiraki M, Hayashi T, Nakamura T. (1987). Reduced occurrence of vertebral crush fractures in senile osteoporosis treated with 1 alpha (OH)-vitamin D3. Bone Miner.
386 Orimo H, Shiraki M, Hayashi Y, Hoshino T, Onaya T, Miyazaki S, Kurosawa H, Nakamura T, Ogawa N. (1994). Effects of 1 alpha-hydroxyvitamin D3 on lumbar bone mineral density and vertebral fractures in patients with postmenopausal osteoporosis. Calcif Tissue Int.
387 Orloff, D. G. NDA 21–318 [FDA approval letter]. Center for Drug Research and Evaluation, Food and Drug Administration. 2003 Jan 15. Rec #: 1090
388 Orwoll ES, Scheele WH, Clancy AD, Adami S, Syversen U, Kaufman MM. (2001). Recombinant human parathyroid hormone(1–34) increases bone mineral density in men with both idopathic and hypogonadal osteoporosis. Arthris Rheum.
389 Osteoporosis Methodology Group and Osteoporosis Research Advisory Group. (2002). Meta-analyses of therapies for postmenopausal osteoporosis. Endocrine Rev.
390 Ott SM, Chesnut CH. (1989). Calcitriol treatment is not effective in postmenopausal osteoporosis. Ann Intern Med.
391 Ott SM, Woodson GC, Huffer WE, Miller PD, Watts NB. (1994). Bone histomorphometric changes after cyclic therapy with phosphate and etidronate disodium in women with postmenopausal osteoporosis. J Clin Endocrinol Metab.
392 Overgaard, K. and Christiansen, C. Long-term treatment of established osteoporosis with intranasal calcitonin. Rec #: 1895
393 Overgaard K, Ravn P, Hansen MA, Christiansen C. (1993). [Salmon calcitonin in osteoporosis. The effect of intranasal application on bone mineral content and fracture frequency in postmenopausal women with manifest osteoporotic changes]. Ugeskrift for Laeger.
394 Overgaard K, Riis BJ, Christiansen C, Hansen MA. (1989). Effect of salcatonin given intranasally on early postmenopausal bone loss. BMJ.
395 Overgaard K, Riis BJ, Christiansen C, Podenphant J, Johansen JS. (1989). Nasal calcitonin for treatment of established osteoporosis. Clin Endocrinol (Oxf).
396 Pacifici R, McMurtry C, Vered I, Rupich R, Avioli LV. (1988). Coherence therapy does not prevent axial bone loss in osteoporotic women: a preliminary comparative study. J Clin Endocrinol Metab.
397 Paganini-Hill A, Ross RK, Gerkins VR, Henderson BE, Arthur M, Mack TM. (1981). Menopausal estrogen therapy and hip fractures. Ann Intern Med.
398 Pagone, F.; Balaguer, A.; Escribano, J.; Feliu, A., and Roquei Figuls, M. Dietary interventions for preventing complications in idiopathic hypercalciuria. Cochrane Database of Systematic Reviews. 2006; (2). Rec #: 3418
399 Pak CY, Sakhaee K, Adams-Huet B, Piziak V, Peterson RD, Poindexter JR. (1995). Treatment of postmenopausal osteoporosis with slow-release sodium fluoride. Final report of a randomized controlled trial. Ann Intern Med.
400 Palmieri GM, Pitcock JA, Brown P, Karas JG, Roen LJ. (1989). Effect of calcitonin and vitamin D in osteoporosis. Calcif Tissue Int.
401 Palmisano, J.; Lewiecki, E. M.; Rosen, C., and et al. Alendronate 70 mg once weekly and alendronate 10 mg once daily preference study in postmenopausal women with osteoporosis [abstract]. 2001; 16, (Suppl 1): S404 Abstract M131. Rec #: 2961
402 Papapoulos SE. (1998). Pharmacological management of osteoporosis. Aging (Milano).
403 Parfitt AM. (1991). Use of bisphosphonates in the prevention of bone loss and fractures. Am J Med.
404 Passeri M, Palummeri E, Barbagallo M, Butturini L, Pedrazzoni M, Davoli L, Pioli G, Benassi L, Girasole G, Ciotti G. (1989). [Sequential calcitriol-calcitonin in the therapy of osteoporosis]. Minerva Endocrinologica.
405 Pastor JF, Valero JL, Marti J, Garcia-Borras JJ, Munoz ML, Caballero M, Aguado C, Alba A, Garcia A. (1997). Clinical trial of ADFR versus calcitonin: Variation of bone metabolism biomarkers. <ORIGINAL> ENSAYO CLINICO ADFR FRENTE A CALCITONINA: VARIACION DE LOS BIOMARCADORES DEL METABOLISMO OSEO. Revista Espanola De Enfermedades Metabolicas Oseas.
406 Pavo I, Masanauskaite D, Rojinskaya L, Smetnik V, Prilepskaya V, Melnichenko G, et al. (1999). Effects of raloxifene (RLX) vs. placebo (PL) on bone mineral density (BMD) in postmenopausal women in the absence of calcium supplementaion [abstract]. J Bone Min Res.
407 Perez EA. (2004). Letrozole in postmenopausal women after five years on tamoxifen. Curr Oncol Rep.
408 Piolini M, Bavazzano A, Bignotti G, et al. (1986). Short-term tolerability of salmon calcitonin and carbocalcitonin. Current Therapeutic Research, Clinical & Experimental.
409 Plosker GL, McTavish D. (1996). Intranasal salcatonin (salmon calcitonin). A review of its pharmacological properties and role in the management of postmenopausal osteoporosis. Drugs Aging.
410 Polatti, F. ; Perotti, F., and et al. Treatment of postmenopausal osteoporosis with salmon calcitonin suppositories. Rec #: 1851
411 Pontiroli AE, Pajetta E, Scaglia L, Rubinacci A, Resmini G, Arrigoni M, Pozza G. (1994). Analgesic effect of intranasal and intramuscular salmon calcitonin in post-menopausal osteoporosis: a double-blind, double-placebo study. Aging (Milan, Italy).
412 Prince R, Devine A, Dick I, Criddle A, Kerr D, Kent N, Price R, Randell A. (1995). The effects of calcium supplementation (milk powder or tablets) and exercise on bone density in postmenopausal women. Journal of Bone and Mineral Research : the Official Journal of the American Society for Bone and Mineral Research.
413 Pruitt LA, Taaffe DR, Marcus R. (1995). Effects of a one-year high-intensity versus low-intensity resistance training program on bone mineral density in older women. Journal of Bone and Mineral Research : the Official Journal of the American Society for Bone and Mineral Research.
414 Pun KK, Chan LW. (1989). Analgesic effect of intranasal salmon calcitonin in the treatment of osteoporotic vertebral fractures. Clinical Therapeutics.
415 Qiu GX, Wu ZH, Shen JX, Luo XZ, Tang H, Wang YP, Weng XS, Yang XY, Lin J, Jin J, Zhao Tian Y, Zhang JG. (2004). [Clinic effect of alendronate sodium treatment in osteoporosis patients with hip fracture]. Zhonghua Wai Ke Za Zhi [Chinese Journal of Surgery].
416 Rachman IA, Hestiantoro A, Baziad A, Moeloek FA, Sumosardjuno S. (1998). Evaluation of certain clinical and laboratory changes in the treatment of post menopause osteoporosis between hormonal replacement + calcium and hormonal replacement + calcium + vitamin D3 and only vitamin D3 + calcium with bearing exercise. J Med Assoc Thai.
417 Ravn P, Bidstrup ME, Bjarnason NH, et al. (1998). Monitoring of treatment and prediction of effect on bone mass by biochemical markers in the early postmenopausal intervention cohort (EPIC) study of alendronate. Osteoporos Int.
418 Ravn P, Overgaard K, Huang C, Ross PD, Green D, McClung M. (1996). Comparison of bone densitometry of the phalanges, distal forearm and axial skeleton in early postmenopausal women participating in the EPIC Study. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
419 Ravn P, Wasnich R, McClung M, et al. (1998). Long-term treatment with alendronate prevents postmenopausal bone loss: EPIC four-year results. Bone.
420 Recker R, Ensrud K, Diem S, et al. (2004). Normal bone histomorphometry and 3 D microarchitecture after 10 years alendronate treatment of postmenopausal women. J Bone Miner Res.
421 Recker R, Masarachia P, Santora A, Howard T, Chavassieux P, Arlot M, Rodan G, Wehren L, Kimmel D. (2005). Trabecular bone microarchitecture after alendronate treatment of osteoporotic women. Curr Med Res Opin.
422 Reeve J, Arlot M, Bernat M, Edouard C, Hesp R, Slovik D, Vismans FJFE, Meunier PJ. (1980). Treatment of osteoporosis with human parathyroid hormone fragment 1–34: a positive final tissue balance in trabecular bone. Metab Bone Dis Rel Res.
423 Reeve J, Davies UM, Hesp R, McNally E, Katz D. (1990). Treatment of osteoporosis with human parathyroid peptide and observations on effect of sodium fluoride. BMJ.
424 Reeve J, Meunier PJ, Parsons JA, Bernat M, Bijvoet OL, Courpron P, Edouard C, Klenerman L, Neer RM, Renier JC, Slovik D, Vismans FJ, Potts JT. (1980). Anabolic effect of human parathyroid hormone fragment on trabecular bone in involutional osteoporosis: a multicentre trial. Br Med J.
425 Reeve, J.; Podbesek, R. D.; Price, T. R.; Arlot, M.; Bartlett, C.; Deacon, A. C.; Edovard, C.; Green, J. R.; Hesp, R.; Hulme, P.; Katz, D.; Tellez, M.; Zanelli, G. D.; Zanelli, J. M., and Meunier, P. J. Studies of a “short-cycle” ADFR regime using parathyroid peptide hPTH 1–34 in idiopathic osteoporosis and in a dog model. Copenhagen: Aalborg Stiftsbogtrykkeri; 1984; pp. 567–573. Rec #: 3111
426 Reginster JY. (1993). Calcitonin for prevention and treatment of osteoporosis. Am J Med.
427 ---. Effect of calcitonin on bone mass and fracture rates. Am J Med. 1991 Nov 25; 91(5B):19S–22S. Rec #: 2691
428 ---. Management of high turnover osteoporosis with calcitonin. Bone. 1992; 13 Suppl 2:S37–40. Rec #: 2689
429 ---. The role of bisphosphonates in the prevention and treatment of osteoporosis. Clin Rheumatol. 1995 Sep; 14 Suppl 3:22–5. Rec #: 2546
430 Reginster JY, Denis D, Bartsch V, Deroisy R, Zegels B, Franchimont P. (1993). Acute biochemical variations induced by four different calcium salts in healthy male volunteers. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
431 Reginster JY, Kaufman JM, Gangjii V. (2005). Preference for and acceptability of two formulations of a dietary supplement containing calcium plus vitamin DSUB3: A randomized, open lable, crossover trial in adult patients with calcium and vitamin D deficiencies. Current Therapeutic Research - Clinical and Experimental.
432 Reginster JY, Meurmans L, Zegels B, Rovati LC, Minne HW, Giacovelli G, Taquet AN, Setnikar I, Collette J, Gosset C. (1998). The effect of sodium monofluorophosphate plus calcium on vertebral fracture rate in postmenopausal women with moderate osteoporosis. A randomized, controlled trial. Ann Intern Med.
433 Reid, D. M. A comparison of Raloxifene HCI and placebo in the treatment of postmenopausal women with osteoporosis. 1999. Rec #: 1654
434 Reid, D. M. ; Hosking, D. J.; Kendler, D. L, and et al. FACTS-international: greater increases in BMD with alendronate once weekly compared to risedronate once weekly. Ann Rheum Dis. 2005; 64(Suppl 1):FRI0410–FRI0410. Rec #: 2066
435 Reid IR. (1999). Pharmacological management of osteoporosis in postmenopausal women: a comparative review. Drugs Aging.
436 Reid IR, Wattie DJ, Evans MC, Stapleton JP. (1996). Testosterone therapy in glucocorticoid-treated men. Arch Intern Med.
437 Resch H, Pietschmann P, Krexner E, Woloszczuk W, Willvonseder R. (1990). Effects of one-year hormone replacement therapy on peripheral bone mineral content in patients with osteoporotic spine fractures. Acta Endocrinol (Copenh).
438 Resch H, Pietschmann P, Willvonseder R. (1989). Estimated long-term effect of calcitonin treatment in acute osteoporotic spine fractures. Calcif Tissue Int.
439 Ribot C, Smith R, Fogelman I. (1999). Risedronate increases bone mineral density and is well-tolerated in postmenopausal women with low bone mineral density. Journal of Bone and Mineral REsearch.
440 Riggs BL, O'Fallon WM, Muhs J, O'Connor MK, Kumar R, Melton LJ. (1998). Long-term effects of calcium supplementation on serum parathyroid hormone level, bone turnover, and bone loss in elderly women. J Bone Miner Res.
441 Ringe JD. (1990). [Treatment of primary osteoporosis with calcium and salmon calcitonin]. Deutsche Medizinische Wochenschrift.
442 Ringe JD, Kipshoven C, Coster A, Umbach R. (1999). Therapy of established postmenopausal osteoporosis with monofluorophosphate plus calcium: dose-related effects on bone density and fracture rate. Osteoporos Int.
443 Ringe JD, Schmid K, Welzel D. (1988). Treatment results in corticoid-induced osteoporosis under salmon calcitonin. Klinische Wochenschrift.
444 Ringe JD, Welzel D. (1987). Salmon calcitonin in the therapy of corticoid-induced osteoporosis. European Journal of Clinical Pharmacology.
445 Roe, E.; Sanchez, S., and del Puerto, G. Parathyroid hormone 1–34 (hPTH1–34) and estrogen produce dramatic bone density increases in postmenopausal osteoporosis—results from a placebo-controlled randomized trial. J Bone Miner Res. 199?; 14(suppl 1):S137. Rec #: 3152
446 Roe E, Sanchez S, Del Puerto G. (1999). Parathyroid hormone (hPTH 1–34) and estrogen produce dramatic bone density increases in postmenopausal osteoporosis: results from a placebo-controlled randomised trial. J Bone Mineral Res.
447 Roe EB, Sanchez SD, Del-Puerto GA. (1999). Parathyroid hormone 1–34 (hPTH 1–34) and estrogen produce bone density increases in postmenopausal osteoporosis: results from a placebo controlled randomized trial. J Bone Miner Res.
448 Roe EB, Sanchez SD, Del Puerto GA. (1999). Parathyroid hormone 1–34 (hPTH 1–34) and estrogen produce dramatic bone density increases in postmenopausal osteoporosis—results from a placebo-controlled randomized trial. J Bone Miner Res.
449 Rosen CJ, Bonnick SAl, Miller PD, et al. (1999). Treatment of osteoporosis in postmenopausal women: alendronate vs intranasal calcitonin. J Bone Miner Res.
450 Rosen CJ, Schnitzer TJ, Weiss SR, et al. (2000). Alendronate vs intranasal calcitonin: 2-year results. J Bone Miner Res.
451 Rossini M, Gatti D, Zamberlan N, Braga V, Dorizzi R, Adami S. (1994). Long-term effects of a treatment course with oral alendronate of postmenopausal osteoporosis. J Bone Miner Res.
452 Rottoli, P. ; Gonnelli, S.; Cappiello, V.; Cepollaro, C.; Pondrelli, C.; Franci, M. B., and Gennari, C. Prevention of steroid-induced osteoporosis with alendronate in sarcoidosis. 1997. Rec #: 1924
453 Rouox C, Miller P, Gennari C, Keller M, Sorensen O, Ritter-Hrncirik C, Barton I, Watts N. (1999). Risedronate rapidly reduces vertebral fracture risk in postmenopausal women with established osteoporosis. Arthritis and Rheumatism.
454 Roux C, Oriente P, Laan R, Hughes RA, Ittner J, Kaufman JM, Di Munno O, Pouilles JM, Horlait S, Cortet B. (1997). Etidronate in the prevention of corticosteroid induced bone loss: a randomized placebo-controlled prospective study. J Bone Min Res.
455 Rubin BR. (1997). Alendronate useful in treating osteoporosis. J Am Osteopath Assoc.
456 Ruml LA, Dubois SK, Roberts ML, Pak CY. (1995). Prevention of hypercalciuria and stone-forming propensity during prolonged bedrest by alendronate. Journal of Bone and Mineral Research : the Official Journal of the American Society for Bone and Mineral Research.
457 Russo MS, Panebianco P, Di Stefano F, Scarpinato RA, Destro G, Salamone SA, Tropea S, Rizzo, A, Maugeri D. (1996). The use of bisphosphonates in the treatment of osteoporosis. Archives of Gerontology & Geriatrics.
458 Saag K, Emkey R, Gruber B, Tesser J, Lane N, Yanover M, Dubois C, Freedholm D, Carofano, W, Daifotis A. (1997). Alendronate for the management of glucocorticoid-induced osteoporosis: results of the multicenter U.S. study. Arthritis Rhem.
459 Saarto, T.; Blomqvist, C.; Taskinen, M. R., and et al. Effect of adjuvant toremifene, a novel antiestrogen on bone mineral density and lipids in postmenopausal women with breast cancer. Breast Cancer Research & Treatment. 46(1):31–31, 1997. 1997. Rec #: 2034
460 Sahin F, Durlanik G, Parlar D, et al. (2000). Comparison of the effects of alendronateand calcitonin on postmenopausal osteoporosis. Osteporos Int.
461 Sairanen S, Tahtela R, Laitinen K, Karonen SL, Valimaki MJ. (1994). Nocturnal rise in markers of bone resorption is not abolished by bedtime calcium or calcitonin. Calcified Tissue International.
462 Sambrook P, Birmingham J, Kelly P. (1993). Prevention of corticosteroid-induced osteoporosis. NEJM.
463 San Martin J. (2004). Treatment of osteoporosis with Teriparatide rhPTH(1–34). J Musculoskelet Neuronal Interact.
464 San Martin, J.; O'Gorman, J.; Eckert, S.; Freedman, M.; Lo, S. C. B.; Walls, E. L., and et al. Digitized mammography in postmenopausal women receiving raloxifene or estrogen in a two-year, placebo-controlled, randomized controlled trial [abstract]. American Society of Clinical Oncology 36th Annual Meeting; New Orleans. Rec #: 1128
465 Sands RH, Studd JW, Jones J, Alaghband-Zadeh J. (2000). Comparison of the biochemical effects of testosterone and estrogen on bone markers in surgically menopausal women. Gynecological Endocrinology :The Official Journal of the International Society of Gynecological Endocrinology.
466 Sarkar, S.; Meunier, P. J.; Vignot, E.; Garnero, P.; Confavreux E., and Liu-Leage, S. et al. [Changes in bone mineral density and serum cholesteral in osteoporotic postmenopausal women treated with raloxifne [abstract]]. The North American Menopause Society 9th Annual Meeting. Rec #: 1105
467 Schmidt WA. (2006). Current diagnosis and treatment of temporal arteritis. Curr Treat Options Cardiovasc Med.
468 Schneider EL, Guralnik JM. (1990). The aging of America. Impact on health care costs. JAMA.
469 Schnitzer T, Bone HG, Crepaldi G, Adami S, McClung M, Kiel D, Felsenberg D, Recker RR, Tonino RP, Roux C, Pinchera A, Foldes AJ, Greenspan SL, Levine MA, Emkey R, Santora AC, Kaur A, Thompson DE, Yates J, Orloff JJ. (2000). Therapeutic equivalence of alendronate 70 mg once-weekly and alendronate 10 mg daily in the treatment of osteoporosis. Alendronate Once-Weekly Study Group. Aging (Milano).
470 Schulz KF, Chalmers I, Hayes RJ, Altman DG. (1995). Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA.
471 Seeman, E. Alendronate increases BMD and reduces fracture risks. 1996. Rec #: 1927
472 Sellmeyer DE, Palermo L, Bouxsein ML, et al. (2004). Hetergeneity in skeletal response to full-length parathyroid hormone (PTH). J Bone Miner Res.
473 Seyisoglu, H.; Erel, T.; Yalcinkaya, T.; Colgar, U., and Ertungealp, E. The effect of prophylactic calcitonin use on bone metabolism during early menopausal period. Jinekol. 1994; OBSTET. DERG. 8(1):11–16. Rec #: 1790
474 Sharma RK, Jeloka T. Gupta A. Gupta S. Gulati S. Kapoor R. Srivastava A. Effect of alendronate of post renal transplant osteoporosis: a randomised study. 2004. Rec #: 1366
475 Shiraki M, Kushida K, Fukunaga M, Kishimoto H, Kaneda K, Minaguchi H, Inoue T, Tomita A, Nagata Y, Nakashima M, Orimo H. (1998). A placebo-controlled, single-blind study to determine the appropriate alendronate dosage in postmenopausal Japanese patients with osteoporosis. The Alendronate Research Group. Endocr J.
476 Shrader SP, Ragucci KR. (2005). Parathyroid hormone (1–84) and treatment of osteoporosis. Ann Pharmacother.
477 Shukla, V. K. Treating osteoporosis with teriparatide: many unknowns? Issues Emerg Health Technol. 2003 Nov; (51):1–4. Rec #: 2222
478 Sileghem A, Geusens P, Dequeker J. (1992). Intranasal calcitonin for the prevention of bone erosion and bone loss in rheumatoid arthritis. Annals of the Rheumatic Diseases.
479 Silverberg SJ, Shane E, de la Cruz L, Dempster DW, Feldman F, Seldin D, Jacobs TP, Siris ES, Cafferty M, Parisien MV, et al. (1989). Skeletal disease in primary hyperparathyroidism. J Bone Miner Res.
480 Simon JA, Hunninghake DB, Agarwal SK, Lin F, Cauley JA, Ireland CC, Pickar JH. (2001). Effect of estrogen plus progestin on risk for biliary tract surgery in postmenopausal women with coronary artery disease. The Heart and Estrogen/progestin Replacement Study. Ann Intern Med.
481 Sisson de Castro JA. (1996). Alendronate treatment of osteoporosis in men. Short term bone mass response. J Bone Miner Res.
482 Slovik DM, Neer RM, Potts JT. (1981). Short-term effects of synthetic human parathyroid hormone-(1—34) administration on bone mineral metabolism in osteoporotic patients. J Clin Invest.
483 Smith, M.; Price, R.; Prince, R.; Lawson, N.; Chute, C., and Dick, I. A randomized, placebo controlled, double blind study of osteoporosis prevention. 1988. Rec #: 1697
484 Smith MD, Cheah SP, Taylor K, Ahern MJ. (2001). Prevention of corticosteroid induced osteoporosis in inpatients recently discharged from a tertiary teaching hospital. J Rheumatol.
485 Somboonporn, W.; Davis, S.; Bell, R., and Seif, M. W. Testosterone for peri- and postmenopausal women. Cochrane Database of Systematic Reviews. 2005(3). Rec #: 1998
486 Sorensen O, Goemare S, Wenderoth D. (2003). Sustained effect of risedronate: a 7-year study in postmenopausal women. Calcif Tissue Int.
487 Sorensen, O. H.; Kollerup, G., and et al. Effect of long-term etidronate treatment on bone mass and spinal fracture rate. 1996. Rec #: 1627
488 Sosa M, Navarro MC, Hernandez D, et al. (2000). Alendronate produces a greater increase in BMD than calcitriol in postmenopausal osteoporotic women. Bone.
489 Ste-Marie, G. and Scheele, W. H. Effect of LY333334 and estrogen jproduce dramatic bone density increases in postmenopausal osteoporosis—results from a placebo-controlled randomized trial. J Clin Endocrinol Metab. 2001; (suppl):39509. Rec #: 3043
490 Ste-Marie, L. G.; Scheele, W. H.; Clancy, A. D.; Jasqui, S., and Gaich, G. A. Effect of recombinant human parathyroid hormone (1–34) on bone density when given to postmenopausal women receiving hormone replacement therapy. 2002. Rec #: 1171
491 Stefanick ML. (1999). The postmenopausal estrogen-progestin interventions (PEPI) trial. Infertility and Reproductive Clinics of North America.
492 Stepan J, Formankova J, Masatova A, Michalsky M, Rosenova Z. (1997). Efficacy of 17beta-estradiol and calcitonin in postmenopausal women with bone loss. <ORIGINAL> POROVNANI UCINNOSTI LECBY 17beta-ESTRADIOLEM A KALCITONINEM U ZEN S UBYTKEM KOSTNI HMOTY PO MENOPAUZE. Casopis Lekaru Ceskych.
493 Stevenson, J. C. Prevention of postmenopausal osteoporosis by calcitonin. Rec #: 1946
494 Stevenson JC, Abeyasekera G, Hillyard CJ, Phang KG, MacIntyre I, Campbell S, Townsend PT, Young O, Whitehead MI. (1981). Calcitonin and the calcium-regulating hormones in postmenopausal women: effect of oestrogens. Lancet.
495 Stewart AF. (1996). PTHrP(1–36) as a skeletal anabolic agent for the treatment of osteoporosis. Bone.
496 Stock J, Johnell O, Scheele W, Lu Y, Lakshaman M. (1999). Effects of raloxifiene (RLX), alendronate (ALN) and RLX+ALN on bone mineral density and biochemical markers of bone turnover in postmenopausal with osteoporosis [abstract]. Arthritis Rheum.
497 Storm, T.; Thamsborg, G., and et al. Long-term effect of intermittent etidronate therapy for postmenopausal osteoporosis. 1993. Rec #: 1722
498 Storm T, Thamsborg G, Steiniche T, et al. (1990). Etidronate for postmenopausal osteoporosis. N Engl J Med.
499 Studd JW, Baber RJ. (1988). Calcitonin for postmenopausal bone loss. Lancet.
500 Taylor Y, Johnson S, Watts S, Mitchell B, Plouffe L. (2002). Effect of 4 years of raloxifene therapy on endometrial hyperplasia and endometrial cancer in postmenopausal women with osteoporosis (abstract). Climacteric.
501 Thamsborg G, Storm TL, Sykulski R, Brinch E, Nielsen HK, Sorensen OH. (1991). Effect of different doses of nasal salmon calcitonin on bone mass. Calcif Tissue Int.
502 Thiebaud D, Goldstein S, Srikanth R, Parson A, Londono J, Kenemans P, et al. (1999). Effects of raloxifene, estrogen and placebo on the postmenopausal endometrium: a 12- month comparative study [abstarct]. Climacteric.
503 Thiebaud, D.; Kriegbaum, H., and et al. Intravenous injections of ibandronate (IB) in the treatment of postmenopausal osteoporosis. 1996. Rec #: 1271
504 Thomas T, Lafage MH, Alexandre C. (1995). Atypical osteomalacia after 2 year etidronate intermittent cyclic administration in osteoporosis. J Rheumatol.
505 Tilyard MW, Spears GF, Thomson J, Dovey S. (1992). Treatment of postmenopausal osteoporosis with calcitriol or calcium. N Engl J Med.
506 Tonino RP; Santora A, and Ross PD. Safety of long-term alendronate. J Clin Endocrinol Metab. 2001; 86(1835–6). Rec #: 2881
507 Tripathy AD, Diel I, Body JJ. (2004). Ibandronate reduces skeletal morbidity in patients with breast cancer. Semin Oncol.
508 Tsakalakos N, Magiasis B, Tsekoura M, Lyritis G. (1993). The effect of short-term calcitonin administration on biochemical bone markers in patients with acute immobilization following hip fracture. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
509 Tucker G. (2003). Risks of estrogen plus progestin therapy: a sensitivity analysis of findings in the Women's Health Initiative randomized trial: comments from reviewer. Climacteric.
510 Uusi-Rasi K, Beck TJ, Oresfovich E. (2002). Teriparatide (rhPTH 1–34) improves the structural geometry of the hip. J Bone Miner Res.
511 Uusi-Rasi K, Sievanen H, Kannus P, et al. (2001). Effects of oral alendronate and exercise on tibia and physical performance in early postmenopausal women. J Bone Miner Res.
512 Vahle, J. L.; Long, G. G.; Sandusky, G.; Westmore, M.; Ma, Y. L., and Sato, M. Bone neoplasms in F344 rats given teriparatide. Toxicol Pathol. 2004 Jul–2004 Aug 31; 32(4):426–38. Rec #: 2876
513 Vahle, J. L.; Sato, M.; Long, G. G.; Young, J. K.; Francis, P. C.; Engelhardt, J. A.; Westmore, M. S.; Linda, Y., and Nold, J. B. Skeletal changes in rats given daily subcutaneous injections of recombinant human parathyroid hormone (1–34) for 2 years and relevance to human safety. Toxicol Pathol. 2002 May–2002 Jun 30; 30(3):312–21. Rec #: 2874
514 Vehmanen L. (1999). The effect of adjuvant clodronate on bone mineral density (BMD) in pre- and postmenopausal breast cancer patients. A randomized 5 yr. follow-up study. European Journal of Cancer.
515 Vignot E, Meunier PJ. (1999). [Effects of raloxifene on bone loss and fracture risk in the menopausal woman]. Contraception, Fertilite, Sexualite (1992).
516 Voskaridou E, Terpos E, Spina G, Palermos J, Rahemtulla A, Loutradi A, Loukopoulos D. (2003). Effect of pamidronate on bone remodeling in adult patients with beta-thalassemia major and osteoporosis. Bone.
517 ---. Pamidronate is an effective treatment for osteoporosis in patients with thalassemia major. 2003. Rec #: 1233
518 Vyskocil V, Vyskocilova J, Topolcan O, et al. (2000). The effect of alendronat treatment in men with primary and steroid-induced osteoporosis. Bone.
519 ---. The effect of alendronate treatment in men with primary and steroid-induced osteoporosis. Osteoporosis Int. 2000 Jun; 11(Suppl 2):545. Rec #: 2128
520 Waldegger, L.; Cranney, A.; Adachi, J. D.; Tugwell, P., and Wells, G. Human parathyroid hormone for the treatment of osteoporosis in post-menopausal women. Cochrane Database of Systematic Reviews. 2005(3). Rec #: 1173
521 Wang L, Hu W, Bai RY, Kong DC. (2001). Clinical efficacy of bisphosphonates in the treatment of postmenopausal osteoporosis. Chinese Journal of Orthopaedics.
522 Warburton, E. A. Intravenous bisphosphonates in the prevention of osteoporosis associated with stroke. 2003. Rec #: 1287
523 Watts M, Roux V, Genant H. (1999). Risedronate reduces vertebral fracture risk after the first year of treatment in postmenopausal women with extablished osteoporosis. Journal of Bone and Mineral Research.
524 Watts N, Freedholm D, Daifotis A. (1999). The clinical tolerability profile of alendronate. Int J Clin Pract Suppl.
525 Watts N, McClung M, Olsynski W. (2004). Effects of risedronate discontinuation on bone turnover and bone mineral density in postmenopausal women with osteoporosis. J Clin Densitom.
526 Watts, N. B.; Adami, S., and Chesnut, C. H. Risedronate reduces the risk of clinical vertebral fractures in just 6 months. 2001; 16, (suppl 1): S407. Rec #: 3130
527 Watts, N. B.; Sorensen, O., and Eriksen E. Risedronate therapy for postmenopausal osteoporosis reduces vertebral and nonvertebral fractures after 5 years and results in normal bone histology. American College of Rhematology, 65th Annual Scientific Meeting; San Francisco. Rec #: 3057
528 Watts, N. B.; Worley, K.; Doyle, J. J., and et al. Fracture efficacy within six months for bisphosphonates compared to nasal calcitonin in an observational setting. Endocrine Society's 85th Annual Meeting; Philadelphia, PA. v. P2–510). Rec #: 2079
529 Weinstein R, Meunier PJ, Geusens P, et al. (2001). Skeletal benefits are maintained through 7 years of alendronate treatment. J Bone Miner Res.
530 Whitfield J, Morley P, Willick G. (2000). The parathyroid hormone, its fragments and analogues—potent bone-builders for treating osteoporosis. Expert Opin Investig Drugs.
531 Whitfield JF. (2001). The bone growth-stimulating PTH and osteosarcoma. Medscape Womens Health.
532 Whitfield, J. F.; Morley, P., and Willick, G. E. The parathyroid hormones: bone-forming agents for treatment of osteoporosis. Medscape Womens Health. 2000 Sep–2000 Oct 31; 5(5):E5. Rec #: 2294
533 Wilkinson JM, Stockley I, Peel NF, Hamer AJ, Elson RA, Barrington NA, Eastell R. (2001). Effect of pamidronate in preventing local bone loss after total hip arthroplasty: a randomized, double-blind, controlled trial. J Bone Miner Res.
534 Wimalawansa SJ. (2001). Efficacy of once a week risedronate in comparison with once-weekly alendronate therapy for postmenopausal osteoporosis: one-year data. J Bone Res.
535 Wimalawansa SJ. (1993). Long- and short-term side effects and safety of calcitonin in man: a prospective study. Calcif Tissue Int.
536 Worley K, Doyle JJ, Klemens A, et al. (2003). Incidence of gastrointestinal events among patients with osteoporosis treated with alendronate versus risedronate. Endocrine Pratice.
537 Wright CD, Mansell RE, Gazet JC, Compston JE. (1993). Effect of long term tamoxifen treatment on bone turnover in women with breast cancer. BMJ.
538 Xianzheng, L.; Baojun, W., and Sumei, R. Treatment of osteoporosis with eel calcitonin. Rec #: 1740
539 Yamauchi M, Fukunaga Y. et al. Effect of combination therapy with vitamin D3, vitamin K2, or etidronate on bone mineral density in Japanese patients with non-insulin-dependent diabetes mellitus. 1997. Rec #: 1567
540 Yang HZ, Kuang J, Pei JH. (2001). [Influence of salmon calcitonin on bone mineral density of osteoporosis patients]. Chinese Journal of Practical Internal Medicine.
541 Yu CL, Chem WM, Xu W, Xu JH, Liu SW, Wu SG. (1997). Clinical trial of disodium etidronate in treatment of 180 cases of osteoporosis. Chinese Journal of Osteoporsis.
542 Zanchetta JR, Bogado CE, Ferretti JL, Wang O, Wilson MG, Sato M, Gaich GA, Dalsky GP, Myers SL. (2003). Effects of teriparatide. J Bone Miner Res.
543 Zanchetta JR, Spivacow R, Rey P, et al. (1997). Incidence of adverse effects in osteoporotic patients treated with alendronate. J Bone Miner Res.

## REJECTED: Article too expensive

1 Jaffe RB. (2006). Monthly oral obandronate is well tolerated and efficacious in postmenopausal women: Results from the monthly oral pilot study: Commentary. Obstetrical and Gynecological Survey.
2 Lee PE, McElhaney JE, Dian L. (2006). Calcium and vitamin D supplementation for the prevention of fractures in postmenopausal women. Aging Health.
3 Lofthouse M. (2006). Efficacy of raloxifene and teriparatide in patients with osteoporosis. Nature Clinical Practice Endocrinology and Metabolism.

## REJECTED: Not retrieved by cut-off date

1 Alendronate reduced new fractures in postmenopausal women who had low bone-mineral density and existing vertebral fractures. 1998. Rec #: 1222
2 Alendronate reduced new vertebral fractures in postmenopausal osteoporosis. Rec #: 1266
3 Aoyagi K, Shiraki M, Ito M, et al. (2001). Alendronate is much more effective than calcitonin and alfacalcidol for preventing nonvertebral fractures. Bone.
4 Chesnut C, Baylink DJ, Doyle D. (1998). Salmon-calcitonin nasal spray prevents vertebral fractures in established osteoporosis: further interim results of the PROOF study. Osteoporosis Int.
5 Dissemination, C. f. R. a. Calcium for prevention of osteoporotic fractures in postmenopausal women (Structured abstract). Database of Abstracts of Reviews of Effects. 2006; (2). Rec #: 3422
6 ---. A systematic review of the skeletal effects of estrogen therapy in postmenopausal women - II: an assessment of treatment effects (Structured abstract). Database of Abstracts of Reviews of Effects. 2006; (2). Rec #: 3248
7 Dursun N, Dursun E, Yalcin S. (2001). Comparison of alendronate, calcitonin and calcium treatments in postmenopausal osteoporosis. Int J Clin Pract.
8 Finkelstein JS, Hayes A, Hunzelman JL. (2003). The effects of parathyroid hormone, alendronate, or both in men with osteoporosis. N Engl J Med.
9 Kendler D, Sorensen O, Mulder H, Hodsman A, Drandi M, Bosch L, Valen D, Wenderoth D. (1999). Risedronate reduces the incidence of clinical fractures in postmenopausal women". Arthritis and Rheumatism.
10 Nzeusseu Toukap A, Depresseux G, Devogelaer JP, Houssiau FA. (2005). Oral pamidronate prevents high-dose glucocorticoid-induced lumbar spine bone loss in premenopausal connective tissue disease (mainly lupus) patients. Lupus.

## REJECTED: Design - not RCT or RCT+OLE

1 1 year of alendronate after 1 year of parathyroid hormone (1–84) treatment increased bone mineral density in osteoporosis. ACP Journal Club. 2006; 144(1):10. Rec #: 3267
2 1000 mg calcium and 400 IU vitamin D not very effective for fracture prevention. J Fam Pract. 2006 May; 55(5):386. Rec #: 3380
3 1999 - Raloxifene reduced the incidence of breast cancer in postmenopausal women with osteoporosis. ACP Journal Club. 1999; 131:58. Rec #: 1180
4 Alendronate (Fosamax) and risedronate (Actonel) revisited. Med Lett Drugs Ther. 2005 Apr 25; 47(1207):33–5. Rec #: 2367
5 Alendronate (Fosamax) and risedronate (Actonel) revisited. Obstet Gynecol. 2005 Aug; 106(2):402–4. Rec #: 2360
6 Alendronate increased bone mineral density and decreased vertebral fractures in men with osteoporosis. ACP Journal Club. 2001 Mar–2001 Apr 30; 134(2):64. Rec #: 1197
7 ALX 111: ALX1–11, parathyroid hormone (1–84) - NPS Allelix, PREOS, PTH, recombinant human parathyroid hormone, rhPTH (1–84). Drugs R D. 2003; 4(4):231–5. Rec #: 2237
8 Calcium/vitamin D not effective for secondary prevention of fracture. J Fam Pract. 2005 Aug; 54(8):658. Rec #: 3394
9 Choice of drugs for postmenopausal osteoporosis. Med Lett Drugs Ther. 1992 Oct 30; 34(882):101–2. Rec #: 2682
10 Combining PTH and alendronate: no advantage for boosting bone density. FDA Consum. 2003 Nov–2003 Dec 31; 37(6):8. Rec #: 2209
11 Cyclical etidronate treatment of osteoporosis. N Engl J Med. 1990 Dec 6; 323(23):1633–5. Rec #: 2575
12 Drugs for prevention and treatment of postmenopausal osteoporosis. Treat Guidel Med Lett. 2002 Nov; 1(3):13–8. Rec #: 2175
13 Etidronate, calcium, or both did not reduce fracture rates in patients with asthma receiving glucocorticoid treatment. ACP Journal Club. 2005 Mar–2005 Apr 30; 142(2):44. Rec #: 1167
14 Etidronate, calcium, or both did not reduce fracture rates in patients with asthma receiving glucocorticoid treatment [Therapeutics]. ACP Journal Club March/April. 2005; 142(2):44. Rec #: 3336
15 Etidronate for vertebral osteoporosis after the menopause. Drug Ther Bull. 1992 Jun 8; 30(12):45–6. Rec #: 2568
16 Forteo approved for osteoporosis treatment. FDA Consum. 2003 Mar–2003 Apr 30; 37(2):4. Rec #: 2243
17 Ibandronate (Boniva): a new oral bisphosphonate. Obstet Gynecol. 2005 Aug; 106(2):404. Rec #: 2359
18 Intravenous ibandronate (Boniva). Med Lett Drugs Ther. 2006 Aug 14–2006 Aug 28; 48(1241–1242):68–9. Rec #: 3549
19 New drug approved for treating osteoporosis. Mayo Clin Womens Healthsource. 2003 May; 7(5):3. Rec #: 2244
20 New drug builds bone. Harv Womens Health Watch. 2001 Jul; 8(11):2. Rec #: 2281
21 New osteoporosis strategy: boosting bone growth. Johns Hopkins Med Lett Health After 50. 2004 Apr; 16(2):4—5. Rec #: 2202
22 NIH Consensus Development Panel on Osteoporosis Prevention, Diagnosis, and Therapy, March 7–29, 2000: highlights of the conference. South Med J. 2001 Jun; 94(6):569–73. Rec #: 2940
23 Once-monthly ibandronate effective for postmenopausal osteoporosis. Geriatrics. 2005; 61(11):18. Rec #: 3467
24 Parathyroid hormone (1–34) alone was better than parathyroid hormone plus alendronate in men with osteoporosis. ACP Journal Club. 2004 May–2004 Jun 30; 140(3):63. Rec #: 1133
25 Parathyroid hormone (1–84) plus alendronate was not better than monotherapy with either agent in postmenopausal osteoporosis. ACP Journal Club. 2004 May–2004 Jun 30; 140(3):62. Rec #: 1182
26 Parathyroid hormone decreased fracture rates and increased bone mineral density in postmenopausal women. ACP Journal Club. 2001 Nov–2001 Dec 31; 135(3):95. Rec #: 1194
27 Raloxifene and prevention of vertebral fracture (cont'd): mainly when oestrogen is contraindicated. Prescrire Int. 2000 Dec; 9(50):190–1. Rec #: 2605
28 Raloxifene reduced vertebral fractures in postmenopausal women. ACP Journal Club. 2000 Mar–2000 Apr 30; 132(2):58. Rec #: 1212
29 Raloxifene to prevent postmenopausal osteoporosis. Drug Ther Bull. 1999 May; 37(5):33–6. Rec #: 2611
30 Recommendations for the prevention and treatment of glucocorticoid-induced osteoporosis: 2001 update. American College of Rheumatology Ad Hoc Committee on Glucocorticoid-Induced Osteoporosis. Arthritis Rheum. 2001 Jul; 44(7):1496–503. Rec #: 2735
31 Risedronate lowers risk of first fracture. Pharmaceutical Journal. 2002; 268(7202):829. Rec #: 3473
32 Risedronate: Significant reduction in fracture risk seen, 74% at 1 year. Formulary. 2002; 37 (8):383. Rec #: 3474
33 Risedronate was effective and well tolerated in postmenopausal women with osteoporosis. ACP Journal Club. 2000 Jul–2000 Aug 31; 133(1):15. Rec #: 1202
34 Skeletal effects of oestrogen and testosterone in postmenopausal women. BMJ. 1988 Sep 10; 297(6649):687–8. Rec #: 2757
35 Summaries for patients. Alendronate improves osteoporosis in elderly women living in long-term care facilities. Ann Intern Med. 2002 May 21; 136(10):I54. Rec #: 2451
36 Teriparatide for postmenopausal osteoporosis. Drug Ther Bull. 2004 Dec; 42(12):93–5. Rec #: 2171
37 Teriparatide (forteo) for osteoporsis. Med Lett Drugs Ther. 2003 Feb 3; 45(1149):9–10. Rec #: 2253
38 Teriparatide. LY 333334, MN 10T, parathyroid hormone (1–34), parathyroid hormone (1–34)-Asahi, parathyroid hormone (1–34)-Eli Lilly, parathyroid hormone (1–34)-Rhone-Poulenc Rorer, teriparatide acetate, hPTH 1–34, Parathar. Drugs R D. 1999 Mar; 1(3):222–4. Rec #: 2304
39 Teriparatide: new preparation. Osteoporosis: less well evaluated than alendronic acid. Prescrire Int. 2005 Feb; 14(75):5–9. Rec #: 2166
40 Testosterone supplementation therapy for older men: potential benefits and risks (Structured abstract). Database of Abstracts of Reviews of Effectiveness. 2005(3). Rec #: 1999
41 Abdelmalek MF, Douglas DD. (1996). Alendronate-induced ulcerative esophagitis. Am J Gastroenterol.
42 Abdulla AJ. (2000). Use of pamidronate for acute pain relief following osteoporotic vertebral fractures. Rheumatology (Oxford).
43 Adachi J, Cranney A, Goldsmith CH, Bensen WG, Bianchi F, Cividino A, Craig GL, Kaminska E, Sebaldt RJ, Papaioannou A, et al. (1994). Intermittent cyclic therapy with etidronate in the prevention of corticosteroid induced bone loss. J Rheumatol.
44 Adachi JD. (1997). Corticosteroid-induced osteoporosis. Am J Med Sci.
45 Adachi JD, Bensen WG, Bell MJ, Bianchi FA, Cividino AA, Craig GL, Sturtridge WC, Sebaldt RJ, Steele M, Gordon M, Themeles E, Tugwell P, Roberts R, Gent M. (1997). Salmon calcitonin nasal spray in the prevention of corticosteroid-induced osteoporosis. Br J Rheumatol.
46 Adachi JD, Rizzoli R, Boonen S, Li Z, Meredith MP, Chesnut CH. (2005). Vertebral fracture risk reduction with risedronate in post-menopausal women with osteoporosis: a meta-analysis of individual patient data. Aging Clin Exp Res.
47 Adachi JD, Roux C, Pitt PI, Cooper C, Moniz C, Dequeker J, Ioannidis G, Cawley MI, Jenkins EA, Walker-Bone KE, Pack S, Stephenson GF, Laan RF, Brown J, Geusens P. (2000). A pooled data analysis on the use of intermittent cyclical etidronate therapy for the prevention and treatment of corticosteroid induced bone loss. J Rheumatol.
48 Adachi R. (2005). Alendronate reduced clinical and radiographic vertebral fractures in postmenopausal women with osteopenia. ACP J Club.
49 Adami S. (1998). Alendronate in the treatment of osteoporosis. Aging (Milano).
50 Adami S, Isaia G, Luisetto G, Minisola S, Sinigaglia L, Gentilella R, Agnusdei D, Iori N, Nuti R. (2006). Fracture incidence and characterization in patients on osteoporosis treatment: the ICARO study. J Bone Miner Res.
51 Adami S, Prizzi R, Colapietro F. (2001). Alendronate for the treatment of osteoporosis in men. Calcif Tissue Int.
52 Adami S, Viapiana O. (2003). Ibandronate: new options in the treatment of osteoporosis. Drugs Today (Barc).
53 Adami S, Viapiana O, Gatti D. (2004). Bone anabolic agents: the unanswered queries. Basic Clin Pharmacol Toxicol.
54 Adami S, Zamberlan N. (1996). Adverse effects of bisphosphonates. A comparative review. Drug Saf.
55 Adami S, Zamberlan N, Mian M, Dorizzi R, Rossini M, Braga B, Gatti D, Bertoldo F, Locascio V. (1994). Duration of the effects of intravenous alendronate in postmenopausal women and in patients with primary hyperparathyroidism and Paget's disease of bone. Bone Miner.
56 Adler RA, Hochberg MC. (2003). Suggested guidelines for evaluation and treatment of glucocorticoid-induced osteoporosis for the Department of Veterans Affairs. Arch Intern Med.
57 Agnusdei D. (1999). Clinical efficacy of raloxifene in postmenopausal women. European Journal of Obstetrics, Gynecology, & Reproductive Biology.
58 Akcay MN, Akcay G, BIlen H. (2004). The effects of calcitonin on bone resorption in hyperthyroidism: a placebo-controlled clinical study. Journal of Bone and Mineral Metabolism.
59 Aki S, Eskiyurt N, Akarirmak U, Tuzun F, Eryavuz M, Alper S, Arpacioglu O, Atalay F, Kavuncu V, Kokino S, Kuru O, Nas K, Ozerbil O, Savas G, Sendur OF, Soy D, Akyuz G. (2003). Gastrointestinal side effect profile due to the use of alendronate in the treatment of osteoporosis. Yonsei Med J.
60 Ali PA, al-Ghorabie FH, Evans CJ, el-Sharkawi AM, Hancock DA. (1998). Body composition measurements using DXA and other techniques in tamoxifen-treated patients. Applied Radiation and Isotopes : Including Data, Instrumentation and Methods for Use in Agriculture, Industry and Medicine.
61 Alkhenizan A, Almarri S, Evans MF. (2001). Alendronate and male osteoporosis. Can Fam Physician.
62 Almustafa M, Doyle FH, Gutteridge DH, Hand DJ, Davis TM, Spinks TJ, Freemantle C, Joplin GF. (1992). Effects of treatments by calcium and sex hormones on vertebral fracturing in osteoporosis. Q J Med.
63 Aminorroaya A, Kelleher S, Conway AJ, Ly LP, Handelsman DJ. (2005). Adequacy of androgen replacement influences bone density response to testosterone in androgen-deficient men. Eur J Endocrinol.
64 Anderson FH, Francis RM, Bishop JC, Rawlings DJ. (1997). Effect of intermittent cyclical disodium etidronate therapy on bone mineral density in men with vertebral fractures. Age Ageing.
65 Anderson FH, Francis RM, Faulkner K. (1996). Androgen supplementation in eugonadal men with osteoporosis-effects of 6 months of treatment on bone mineral density and cardiovascular risk factors. Bone.
66 Anderson FH, Francis RM, Peaston RT, Wastell HJ. (1997). Androgen supplementation in eugonadal men with osteoporosis: effects of six months' treatment on markers of bone formation and resorption. J Bone Miner Res.
67 Api, M. Prevention of osteoporosis and uterine effects in post-menopausal women taking raloxifene for 5 years. Menopause. 2004 Jul–2004 Aug 31; 11(4):495–6; author reply 496–7. Rec #: 2590
68 Arko B, Prezelj J, Komel R, Kocijancic A, Marc J. (2002). No major effect of estrogen receptor beta gene RsaI polymorphism on bone mineral density and response to alendronate therapy in postmenopausal osteoporosis. J Steroid Biochem Mol Biol.
69 Arlen DJ, Lambert K, Ioannidis G, Adachi JD. (2001). Treatment of established bone loss after renal transplantation with etidronate. Transplantation.
70 Atkins CD. (2003). Re: A randomized, placebo-controlled trial of zoledronic acid in patients with hormone-refractory metastatic prostate carcinoma. Journal of the National Cancer Institute.
71 Audran M, Insalaco P. (2003). Parathyroid hormone therapy for osteoporosis. Joint Bone Spine.
72 Avioli, L. V. Calcitonin therapy in osteoporotic syndromes. J Am Med Womens Assoc. 1990 May–1990 Jun 30; 45(3):103–7. Rec #: 2696
73 ---. Calcitonin therapy in osteoporotic syndromes. Rheum Dis Clin North Am. 1994 Aug; 20(3):777–85. Rec #: 2674
74 Azria M. (1997). Treatment with calcitonin for osteoporosis. Ann Rheum Dis.
75 Azria M, Copp DH, Zanelli JM. (1995). 25 years of salmon calcitonin: from synthesis to therapeutic use. Calcif Tissue Int.
76 Bagger YZ, Tanko LB, Alexandersen P, Ravn P, Christiansen C. (2003). Alendronate has a residual effect on bone mass in postmenopausal Danish women up to 7 years after treatment withdrawal. Bone.
77 Bajaj S, Saag KG. (2003). Osteoporosis: evaluation and treatment. Curr Womens Health Rep.
78 Baker DE. (2002). Alendronate and risedronate: what you need to know about their upper gastrointestinal tract toxicity. Rev Gastroenterol Disord.
79 Banks E, Beral V, Reeves G, Balkwill A, Barnes I. (2004). Fracture incidence in relation to the pattern of use of hormone therapy in postmenopausal women. JAMA.
80 Barreira JC, Messina OD, Maldonado-Cocco JA, Roldan EJ. (1997). Site-dependent bone mineral density response to oral pamidronate and calcium in postmenopausal osteoporosis: a preliminary report. Clin Rheumatol.
81 Barrett-Connor E, Stuenkel CA. (2001). Hormone replacement therapy (HRT)—risks and benefits. Int J Epidemiol.
82 Barrett-Connor E, Wenger NK, Grady D, Mosca L, Collins P, Kornitzer M, Cox DA, Moscarelli E, Anderson PW. (1998). Hormone and nonhormone therapy for the maintenance of postmenopausal health: the need for randomized controlled trials of estrogen and raloxifene. J Womens Health.
83 Barthel HR, Vieth R. (2004). Lack of generalizable evidence of the superiority of alfacalcidol over plain vitamin D in the treatment of glucocorticoid-induced osteoporosis: comment on the article by Ringe et al. Rheumatol Int.
84 Bashore R. (1999). Reduction of vertebral fracture risk with raloxifene. J Fam Pract.
85 Bauer DC. (2004). Combination and sequential therapy with PTH and bisphosphonates. J Musculoskelet Neuronal Interact.
86 Bauer DC, Mundy GR, Jamal SA, Black DM, Cauley JA, Ensrud KE, van der Klift M, Pols HA. (2004). Use of statins and fracture: results of 4 prospective studies and cumulative meta-analysis of observational studies and controlled trials. Arch Intern Med.
87 Bauss F, Russell RG. (2004). Ibandronate in osteoporosis: preclinical data and rationale for intermittent dosing. Osteoporos Int.
88 Bazaldua OV, Bruder J. (2004). Teriparatide (Forteo) for osteoporosis. Am Fam Physician.
89 Beauchesne MF, Miller PF. (1999). Etidronate and alendronate in the treatment of postmenopausal osteoporosis. Ann Pharmacother.
90 Behre HM, Kliesch S, Leifke E, Link TM, Nieschlag E. (1997). Long-term effect of testosterone therapy on bone mineral density in hypogonadal men. J Clin Endocrinol Metab.
91 Behre HM, von Eckardstein S, Kliesch S, Nieschlag E. (1999). Long-term substitution therapy of hypogonadal men with transscrotal testosterone over 7–10 years. Clin Endocrinol (Oxf).
92 Bell NH, Termine JD. (2001). Treatment and prevention of osteoporosis: future directions. J S C Med Assoc.
93 Benshushan A, Brzezinski A. (1999). Tamoxifen effects on menopause—associated risk factors and symptoms. Obstet Gynecol Surv.
94 Beral V, Banks E, Reeves G. (2002). Evidence from randomised trials on the long-term effects of hormone replacement therapy. Lancet.
95 Berg C, Neumeyer K, Kirkpatrick P. (2003). Teriparatide. Nat Rev Drug Discov.
96 Bilezikian JP, Kurland ES. (2001). Therapy of male osteoporosis with parathyroid hormone. Calcif Tissue Int.
97 Bilezikian JP, Morishima A, Bell J, Grumbach MM. (1998). Increased bone mass as a result of estrogen therapy in a man with aromatase deficiency. N Engl J Med.
98 Bilezlkian JP, Silverberg SJ. (2004). Clinical Practice. Asymtomatic primary hyperparathyroidism. N Eng J Med.
99 Biswas PN, Wilton LV, Shakir SA. (2003). Pharmacovigilance study of alendronate in England. Osteoporos Int.
100 Bjarnason NH. (2004). Ten years of alendronate treatment for osteoporosis in postmenopausal women. N Engl J Med.
101 Black DM, Reiss TF, Nevitt MC, Cauley J, Karpf D, Cummings SR. (1993). Design of the Fracture Intervention Trial. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
102 Black DM, Thompson DE, Bauer DC, Ensrud K, Musliner T, Hochberg MC, Nevitt MC, Suryawanshi S, Cummings SR. (2000). Fracture risk reduction with alendronate in women with osteoporosis: the Fracture Intervention Trial. FIT Research Group. J Clin Endocrinol Metab.
103 Blair MM, Carson DS, Barrington R. (2000). Bisphosphonates in the prevention and treatment of glucocorticoid-induced osteoporosis. J Fam Pract.
104 Blank RD, Bockman RS. (1999). A review of clinical trials of therapies for osteoporosis using fracture as an end point. J Clin Densitom.
105 Blau LA, Hoehns JD. (2003). Analgesic efficacy of calcitonin for vertebral fracture pain. Ann Pharmacother.
106 Body JJ. (1995). Calcitonin for prevention and treatment of postmenopausal osteoporosis. Clin Rheumatol.
107 ---. Calcitonin for the long-term prevention and treatment of postmenopausal osteoporosis. Bone. 2002 May; 30(5 Suppl):75S–79S. Rec #: 2644
108 ---. Zoledronic acid: an advance in tumour bone disease therapy and a new hope for osteoporosis. Expert Opin Pharmacother. 2003 Apr; 4(4):567–80. Rec #: 2430
109 Bogaisky M, Leipzig RM. (2005). Calcium and vitamin D supplementation did not reduce fractures in women >/= 70 years of age. ACP J Club.
110 Bogaisky M, Leipzig RM. (2005). Vitamin, D3, calcium, or both did not prevent secondary fractures in elderly people. ACP J Club.
111 Boivin GY, Chavassieux PM, Santora AC, Yates J, Meunier PJ. (2000). Alendronate increases bone strength by increasing the mean degree of mineralization of bone tissue in osteoporotic women. Bone.
112 Bolognese, M.; Fogelman, I., and Guesens, P. Risedronate significantly reduces the risk of non-vertebral fractures in postmenopausal osteoporotic women in just one year. 2001; 16, S404. Rec #: 3058
113 Bone HG, Adami S, Rizzoli R, Favus M, Ross PD, Santora A, Prahalada S, Daifotis A, Orloff J, Yates J. (2000). Weekly administration of alendronate: rationale and plan for clinical assessment. Clin Ther.
114 Bonn D. (2004). New ways with old bones. Osteoporosis researchers look for drugs to replace hormone replacement therapy. Lancet.
115 Boonen S, Bischoff-Ferrari HA, Cooper C, Lips P, Ljunggren O, Meunier PJ, Reginster JY. (2006). Addressing the musculoskeletal components of fracture risk with calcium and vitamin D: a review of the evidence. Calcif Tissue Int.
116 Boonen S, Haentjens P, Vandenput L, Vanderschueren D. (2004). Preventing osteoporotic fractures with antiresorptive therapy: implications of microarchitectural changes. J Intern Med.
117 Boonen S, McClung MR, Eastell R, El-Hajj Fuleihan G, Barton IP, Delmas P. (2004). Safety and efficacy of risedronate in reducing fracture risk in osteoporotic women aged 80 and older: implications for the use of antiresorptive agents in the old and oldest old. J Am Geriatr Soc.
118 Boonen S, Vanderschueren D. (2004). Fracture protection in osteoporosis with risedronate. Hosp Med.
119 Boonen S, Vanderschueren D, Haentjens P, Lips P. (2006). Calcium and vitamin D in the prevention and treatment of osteoporosis - a clinical update. J Intern Med.
120 Borgstrom F, Johnell O, Kanis JA, Oden A, Sykes D, Jonsson B. (2004). Cost effectiveness of raloxifene in the treatment of osteoporosis in Sweden: an economic evaluation based on the MORE study. Pharmacoeconomics.
121 Boyack M, Lookinland S, Chasson S. (2002). Efficacy of raloxifene for treatment of menopause: a systematic review. J Am Acad Nurse Pract.
122 Bradbeer JN, Arlot ME, Meunier PJ, Reeve J. (1992). Treatment of osteoporosis with parathyroid peptide (hPTH 1–34) and oestrogen: increase in volumetric density of iliac cancellous bone may depend on reduced trabecular spacing as well as increased thickness of packets of newly formed bone. Clin Endocrinol (Oxf).
123 Brager R. (1997). Alendronate treatment for osteoporosis. Adv Nurse Pract.
124 Brandenburg, V. M.; Westenfeld, R., and Ketteler, M. The fate of bone after renal transplantation. J Nephrol. 2004 Mar–2004 Apr 30; 17(2):190–204. Rec #: 3406
125 Brandi ML. (2003). Management of post-menopausal osteoporosis: something new on the horizon?. J Endocrinol Invest.
126 Brenckmann, C. and Papaioannou, A. Bisphosphonates for osteoporosis in people with cystic fibrosis. Cochrane Database of Systematic Reviews. 2005(3). Rec #: 1142
127 Breuer B, Subramaniam G, Marchello V, Giambanco V. (1997). A study of the effects of tamoxifen in the frail elderly: difficulties encountered in nursing home research. Women Health.
128 Breuer B, Wallenstein S, Anderson R. (1998). Effect of tamoxifen on bone fractures in older nursing home residents. J Am Geriatr Soc.
129 Brixen KT, Christensen PM, Ejersted C, Langdahl BL. (2004). Teriparatide (biosynthetic human parathyroid hormone 1–34): a new paradigm in the treatment of osteoporosis. Basic Clin Pharmacol Toxicol.
130 Brown JP, Josse RG. (2003). Clinical jpractice guidelines for the diagnosis and management of osteoporosis in Canada. CMAJ.
131 Brown P, Thin CG, Malone DN, Roscoe P, Strong JA. (1970). Metabolic studies with porcine calcitonin in osteoporosis. Scott Med J.
132 Bruyere, O.; Edwards, J., and Reginster, J. Y. Fracture prevention in postmenopausal women. Clin Evid. 2003 Dec; (10):1304–22. Rec #: 2638
133 Buckley LM, Marquez M, Feezor R, Ruffin DM, Benson LL. (1999). Prevention of corticosteroid-induced osteoporosis: results of a patient survey. Arthritis Rheum.
134 Burckhardt P, Burnand B. (1993). The effect of treatment with calcitonin on vertebral fracture rate in osteoporosis. Osteoporos Int.
135 Burger H, Herings RM, Egberts AC, Neef C, Leufkens HG. (2000). Cyclical etidronate use is not associated with symptoms of peptic ulcer disease. Eur J Clin Pharmacol.
136 Buzdar AU, Hortobagyi GN. (1998). Tamoxifen and toremifene in breast cancer: comparison of safety and efficacy. J Clin Oncol.
137 Cadarette SM, Jaglal SB, Hawker GA. (2005). Fracture prevalence and treatment with bone-sparing agents: are there urban-rural differences? A population based study in Ontario, Canada. J Rheumatol.
138 Canatan D, Akar N, Arcasoy A. (1995). Effects of calcitonin therapy on osteoporosis in patients with thalassemia. Acta Haematologica.
139 Cappuzzo KA, Delafuente JC. (2004). Teriparatide for severe osteoporosis. Ann Pharmacother.
140 Capriotti T. (2000). Pharmacologic prevention and treatment of osteoporosis in women. Medsurg Nurs.
141 Cardona JM, Pastor E. (1997). Calcitonin versus etidronate for the treatment of postmenopausal osteoporosis: a meta-analysis of published clinical trials. Osteoporos Int.
142 Casao E, Elosegui LM, Ibanez MA, Vidal MD, Cervera P, Escanero JF. (1995). Short- and long-term effects of calcitonin and calcium administration on blood calcium, magnesium and inorganic phosphorus in post menopausal osteoporosis. J Trace Elem Med Biol.
143 Cauley JA, Robbins J, Chen Z, Cheung AM. (2005). Estrogen/progestin therapy reduced the risk of fracture in postmenopausal women. Evidence-Based Obstetrics and Gynecology.
144 Cauley JA, Seeley DG, Ensrud K, Ettinger B, Black D, Cummings SR. (1995). Estrogen replacement therapy and fractures in older women. Study of Osteoporotic Fractures Research Group. Ann Intern Med.
145 Cauza E, Etemad M, Winkler F, Hanusch-Enserer U, Partsch G, Noske H, Dunky A. (2004). Pamidronate increases bone mineral density in women with postmenopausal or steroid-induced osteoporosis. J Clin Pharm Ther.
146 Cefalu, C. A. Raloxifene therapy in the reduction of fractures. Am Fam Physician. 2000 Mar 1; 61(5):1272, 1275, 1279–80. Rec #: 2609
147 Cetinkaya MB, Kokcu A, Yanik FF, Basoglu T, Malatyalioglu E, Alper T. (2002). Comparison of the effects of transdermal estrogen, oral estrogen, and oral estrogen-progestogen therapy on bone mineral density in postmenopausal women. J Bone Miner Metab.
148 Chailurkit LO, Aunphongpuwanart S, Ongphiphadhanakul B, Jongjaroenprasert W, Sae-tung S, Rajatanavin R. (2004). Efficacy of intermittent low dose alendronate in Thai postmenopausal osteoporosis. Endocr Res.
149 Chan AS. (2004). Ten years of alendronate treatment for osteoporosis in postmenopausal women. N Engl J Med.
150 Chan HW. (2001). Bone builders: preventing and treating osteoporosis. FASEB J.
151 Chan SS, Nery LM, McElduff A, Wilmshurst EG, Fulcher GR, Robinson BG, Stiel JN, Gunton JE, Clifton-Bligh PB. (2004). Intravenous pamidronate in the treatment and prevention of osteoporosis. Intern Med J.
152 Chapurlat RD. (2005). Clinical pharmacology of potent new bisphosphonates for postmenopausal osteoporosis. Treat Endocrinol.
153 Chapurlat RD, Delmas PD. (2006). Drug insight: Bisphosphonates for postmenopausal osteoporosis. Nat Clin Pract Endocrinol Metab.
154 ---. Review of ibandronate in the treatment of osteoporosis. Expert Opin Pharmacother. 2003 Mar; 4(3):391–6. Rec #: 2432
155 Chen B, Mechanick JI, Nierman DM, Stein A. (2001). Combined calcitriol-pamidronate therapy for bone hyperresorption in spinal cord injury. J Spinal Cord Med.
156 Chesnut C, Majumdar S. Gardner J. Shields A. Newitt DC Erickson E. Glott M. Kriegman A. Mindeholm L. Assessment of bone quality, quantity, and turnover with multiple methodologies at multiple skeletal sites. Rec #: 1430
157 Choi HR, Lim SK, Lee MS. (1995). Site-specific effect of testosterone on bone mineral density in male hypogonadism. J Korean Med Sci.
158 Christodoulakos GE, Lambrinoudaki IV, Vourtsi AD, Panoulis KP, Creatsas GC. (2002). Breast pain and mammographic density increase as a consequence of raloxifene therapy. J Endocrinol Invest.
159 Clemett D, Spencer CM. (2000). Raloxifene: a review of its use in postmenopausal osteoporosis. Drugs.
160 Cohen A, Sambrook P, Shane E. (2004). Management of bone loss after organ transplantation. J Bone Miner Res.
161 Cohen SB. (2004). An update on bisphosphonates. Curr Rheumatol Rep.
162 Cohn SH, Dombrowski W, Hauser W, Klopper J, Atkins HL. (1971). Effects of porcine calcitonin on calcium metabolism in osteoporosis. J Clin Endocrinol Metab.
163 Colon-Emeric CS, Caminis J, Suh TT, Pieper CF, Janning C, Magaziner J, Adachi J, Rosario-Jansen T, Mesenbrink P, Horowitz ZD, Lyles KW. (2004). The HORIZON Recurrent Fracture Trial: design of a clinical trial in the prevention of subsequent fractures after low trauma hip fracture repair. Curr Med Res Opin.
164 Compston J. (2005). Recombinant parathyroid hormone in the management of osteoporosis. Calcif Tissue Int.
165 Compston JE. (1999). Alendronate increased bone mineral density but did not reduce new fractures in glucocorticoid induced osteoporosis. Gut.
166 Compston JE. (2000). Pharmacological interventions for the prevention of vertebral and nonvertebral fractures in women with postmenopausal osteoporosis: does site-specificity exist?. Bone.
167 Cortet B. (2004). Combination therapy for osteoporosis. Joint Bone Spine.
168 Cortet B, Bera-Louville A, Gauthier P, Gauthier A, Marchandise X, Delcambre B. (2001). Comparative efficacy and safety study of etidronate and alendronate in postmenopausal osteoporosis. effect of adding hormone replacement therapy. Joint Bone Spine.
169 Cosman F, Lindsay R. (1998). Is parathyroid hormone a therapeutic option for osteoporosis? A review of the clinical evidence. Calcif Tissue Int.
170 ---. Therapeutic potential of parathyroid hormone. Curr Osteoporos Rep. 2004 Mar; 2(1):5–11. Rec #: 2152
171 Coyle D, Cranney A, Lee KM, Welch V, Tugwell P. (2001). Cost effectiveness of nasal calcitonin in postmenopausal women: use of Cochrane Collaboration methods for meta-analysis within economic evaluation. Pharmacoeconomics.
172 Crandall C. (2002). Parathyroid hormone for treatment of osteoporosis. Arch Intern Med.
173 ---. Risedronate: a clinical review. Arch Intern Med. 2001 Feb 12; 161(3):353–60. Rec #: 2473
174 Cranney, A.; Adachi, J.; Guyatt, G.; Papaioannou, A.; Robinson, V.; Shea, B.; Tugwell, P.; Waldegger, L.; Weaver, B.; Wells, G., and Zytaruk, N. Risedronate for the prevention and treatment of postmenopausal osteoporosis [Systematic Review]. Cochrane Database of Systematic Reviews. 2006; (2). Rec #: 3258
175 Cranney, A. ; Adachi, J. D.; Guyatt, G.; Krolicki, N.; Robinson, V. A.; Shea, B. J.; Tugwell, P., and Wells, G. Raloxifene for the prevention and treatment of osteoporosis in post-menopausal women. Cochrane Database of Systematic Reviews. 2005(3). Rec #: 1147
176 Cranney, A. ; Adachi, J. D.; Guyatt, G.; Papaioannou, A.; Robinson, V. A.; Shea, B. J.; Tugwell, P.; Waldegger, L. M.; Weaver, B.; Wells, G., and Zytaruk, N. Risedronate for the prevention and treatment of postmenopausal osteoporosis. Cochrane Database of Systematic Reviews. 2005(3). Rec #: 1130
177 Cranney A, Guyatt G, Griffith L, Wells G, Tugwell P, Rosen C. (2002). Meta-analyses of therapies for postmenopausal osteoporosis. IX: Summary of meta-analyses of therapies for postmenopausal osteoporosis. Endocr Rev.
178 Cranney A, Guyatt G, Krolicki N, Welch V, Griffith L, Adachi JD, Shea B, Tugwell P, Wells G. (2001). A meta-analysis of etidronate for the treatment of postmenopausal osteoporosis. Osteoporos Int.
179 Cranney, A. ; Shea, B.; Wells, B.; Reginster, J. Y.; Adachi, R., and Tugwell, P. Calcitonin for treating osteoporosis in postmenopausal women. Cochrane Database of Systematic Reviews. 2005(3). Rec #: 1221
180 Cranney A, Tugwell P, Zytaruk N, Robinson V, Weaver B, Adachi J, Wells G, Shea B, Guyatt G. (2002). Meta-analyses of therapies for postmenopausal osteoporosis. IV. Meta-analysis of raloxifene for the prevention and treatment of postmenopausal osteoporosis. Endocr Rev.
181 Cranney, A.; Waldegger, L.; Zytaruk, N.; Shea, B.; Weaver, B.; Papaioannou, A.; Robinson, V.; Wells, G.; Tugwell, P.; Adachi, J. D., and Guyatt, G. Risedronate for the prevention and treatment of postmenopausal osteoporosis. Cochrane Database Syst Rev. 2003; (4):CD004523. Rec #: 2412
182 Cranney, A. ; Welch, V.; Tugwell, P.; Wells, G.; Adachi, J. D.; Guyatt, G., and Shea, B. Alendronate for osteoporosis in postmenopausal women. Cochrane Database of Systematic Reviews. 2005(3). Rec #: 1164
183 Crilly RG, Sebaldt RJ, Hodsman AB, Adachi JD, Brown JP, Goldsmith CH, Hanley DA, Olszynski WO, Ste-Marie LG, Stephenson GF. (2000). Predicting subsequent bone density response to intermittent cyclical therapy with etidronate from initial density response in patients with osteoporosis. Osteoporos Int.
184 Croom KF, Scott LJ. (2006). Intravenous ibandronate : in the treatment of osteoporosis. Drugs.
185 Cruz DN, Brickel HM, Wysolmerski JJ, Gundberg CG, Simpson CA, Kliger AS, Lorber MI, Basadonna GP, Friedman AL, Insogna KL, Bia MJ. (2002). Treatment of osteoporosis and osteopenia in long-term renal transplant patients with alendronate. Am J Transplant.
186 Cryer B, Bauer DC. (2002). Oral bisphosphonates and upper gastrointestinal tract problems: what is the evidence?. Mayo Clin Proc.
187 Cummings SR. (2001). The paradox of small changes in bone density and reductions in risk of fracture with raloxifene. Ann N Y Acad Sci.
188 Cummings SR, Black D, Barrett-Connor E, Scott J, Wallace RB. (1999). Alendronate and fracture prevention. JAMA.
189 Cummings SR, Karpf DB, Harris F, Genant HK, Ensrud K, LaCroix AZ, Black DM. (2002). Improvement in spine bone density and reduction in risk of vertebral fractures during treatment with antiresorptive drugs. Am J Med.
190 Cummings SR, Palermo L, Browner W, Marcus R, Wallace R, Pearson J, Blackwell T, Eckert S, Black D. (2000). Monitoring osteoporosis therapy with bone densitometry: misleading changes and regression to the mean. Fracture Intervention Trial Research Group. JAMA : the Journal of the American Medical Association.
191 Curtis, J. R.; Westfall, A. O.; Allison, J. J.; Freeman, A., and Saag, K. G. Channeling and adherence with alendronate and risedronate among chronic glucocorticoid users. Osteoporos Int. 2006. Rec #: 3272
192 Dambacher MA, Olah AJ, Guncaga J, Lentner C, Haas HG. (1971). Calcitonin in human osteoporosis. Results of prolonged administration, assessed by metabolic balance and quantitative histologic techniques. Isr J Med Sci.
193 Davis, L. Prevention of bone loss with alendronate in postmenopausal women under 60 years of age. J Nurse Midwifery. 1998 Sep–1998 Oct 31; 43(5):395–6. Rec #: 2497
194 De Aloysio D, Pansini F, Campobasso C, Zanotti L, Abbruzzese AD, Mauloni M, Bottiglioni F. (1996). Effects of cyclic therapy with intranasal carbocalcitonin in healthy spontaneous postmenopausal women. Clinical and Experimental Obstetrics & Gynecology.
195 de Groen PC, Lubbe DF, Hirsch LJ, Daifotis A, Stephenson W, Freedholm D, Pryor-Tillotson S, Seleznick MJ, Pinkas H, Wang KK. (1996). Esophagitis associated with the use of alendronate. N Engl J Med.
196 de Nijs RN, Jacobs JW, Algra A, Lems WF, Bijlsma JW. (2004). Prevention and treatment of glucocorticoid-induced osteoporosis with active vitamin D3 analogues: a review with meta-analysis of randomized controlled trials including organ transplantation studies. Osteoporos Int.
197 Deal, C. and Gideon, J. Recombinant human PTH 1–34 (Forteo): an anabolic drug for osteoporosis. Cleve Clin J Med. 2003 Jul; 70(7):585–6, 589–90, 592–4 passim. Rec #: 2234
198 Deal, C. L. Risedronate prevents hip fractures, but who should get therapy? Cleve Clin J Med. 2002 Dec; 69(12):964, 968–70, 973–6. Rec #: 2437
199 Dejardin A, Devogelaer JP, Goffin E. (2004). Alendronate versus calcitriol for prevention of bone loss after cardiac transplantation. N Engl J Med.
200 Delaney MF, Hurwitz S, Shaw J, LeBoff MS. (2003). Bone density changes with once weekly risedronate in postmenopausal women. J Clin Densitom.
201 Delling G, Dreyer T, Vogel M, Hahn M, Rittinghaus EF, Hesch RD. (1989). Morphological analysis of iliac crest bone biopsies in patients with osteoporosis and treatment according to the ADFR concept with (1–38)hPTH and diphosphonate (EHDP)—Osteoporosis Study I, Hannover. Klin Wochenschr.
202 Delmas PD. (2002). Different effects of antiresorptive therapies on vertebral and nonvertebral fractures in postmenopausal osteoporosis. Bone.
203 Demerjian N, Bolla G, Spreux A. (1999). Severe oral ulcerations induced by alendronate. Clin Rheumatol.
204 Dempster DW. (2002). The impact of bone turnover and bone-active agents on bone quality: focus on the hip. Osteoporos Int.
205 Dempster DW, Cosman F, Kurland ES, Zhou H, Nieves J, Woelfert L, Shane E, Plavetic K, Muller R, Bilezikian J, Lindsay R. (2001). Effects of daily treatment with parathyroid hormone on bone microarchitecture and turnover in patients with osteoporosis: a paired biopsy study. J Bone Miner Res.
206 Dempster DW, Cosman F, Parisien M, Shen V, Lindsay R. (1993). Anabolic actions of parathyroid hormone on bone. Endocr Rev.
207 Diamond T, Campbell J, Bryant C, Lynch W. (1998). The effect of combined androgen blockade on bone turnover and bone mineral densities in men treated for prostate carcinoma: longitudinal evaluation and response to intermittent cyclic etidronate therapy. Cancer.
208 Diamond T, McGuigan L, Barbagallo S, Bryant C. (1995). Cyclical etidronate plus ergocalciferol prevents glucocorticoid-induced bone loss in postmenopausal women. Am J Med.
209 Diamond T, Stiel D, Posen S. (1991). Effects of testosterone and venesection on spinal and peripheral bone mineral in six hypogonadal men with hemochromatosis. J Bone Miner Res.
210 Diehr S, Mijal S, Nashelsky J. (2005). Raloxifene for prevention of osteoporotic fractures. Am Fam Physician.
211 Dimitrakopoulos I, Magopoulos C, Karakasis D. (2006). Bisphosphonate-induced avascular osteonecrosis of the jaws: a clinical report of 11 cases. Int J Oral Maxillofac Surg.
212 Disla E, Tamayo B, Fahmy A. (1997). Intermittent etidronate and corticosteroid-induced osteoporosis. N Engl J Med.
213 Dissemination, C. f. R. a. The role of vitamin D in corticosteroid-induced osteoporosis: a meta-analytic approach (Structured abstract). Database of Abstracts of Reviews of Effects. 2006; (2). Rec #: 3254
214 ---. VII: Meta-analysis of calcium supplementation for the prevention of postmenopausal osteoporosis (Provisional record). Database of Abstracts of Reviews of Effects. 2006; (2). Rec #: 3426
215 Dissemination, Centre for Reviews and. Analysis of 1-year vertebral fracture risk reduction data in treatments for osteoporosis (Structured abstract). Database of Abstracts of Reviews of Effectiveness. 2005(3). Rec #: 1280
216 ---. Bisphosphonates in the prevention and treatment of glucocorticoid-induced osteoporosis (Structured abstract). Database of Abstracts of Reviews of Effectiveness. 2005(3). Rec #: 1276
217 ---. Calcitonin versus etidronate for the treatment of postmenopausal osteoporosis: a meta-analysis of published clinical trials (Structured abstract). Database of Abstracts of Reviews of Effectiveness. 2005(3). Rec #: 1240
218 ---. Comparing therapies for postmenopausal osteoporosis prevention and treatment (Provisional record). Database of Abstracts of Reviews of Effectiveness. 2005(3). Rec #: 1136
219 ---. Effect of calcitonin on vertebral and other fractures (Structured abstract). Database of Abstracts of Reviews of Effectiveness. 2005(3). Rec #: 1307
220 ---. The effectiveness of bone density measurement and associated treatments for prevention of fractures: an international collaborative review (Structured abstract). Database of Abstracts of Reviews of Effectiveness. 2005(3). Rec #: 1301
221 ---. Evidence-based medicine and osteoporosis: a comparison of fracture risk reduction data from osteoporosis randomised clinical trials (Structured abstract). Database of Abstracts of Reviews of Effectiveness. 2005(3). Rec #: 1273
222 ---. Exercise and regional bone mineral density in postmenopausal women: a meta-analytic review of randomized trials (Structured abstract). Database of Abstracts of Reviews of Effectiveness. 2005(3). Rec #: 1333
223 ---. Exercise for female osteoporosis: a systematic review of randomised clinical trials (Structured abstract). Database of Abstracts of Reviews of Effectiveness. 2005(3). Rec #: 1328
224 ---. Glucocorticoid-induced osteoporosis: guidelines for prevention and treatment (Structured abstract). Database of Abstracts of Reviews of Effectiveness. 2005(3). Rec #: 1269
225 ---. Improvement in spine bone density and reduction in risk of vertebral fractures during treatment with antiresorptive drugs (Structured abstract). Database of Abstracts of Reviews of Effectiveness. 2005(3). Rec #: 1260
226 ---. Meta-analysis about efficacy of anti-resorptive drugs in post-menopausal osteoporosis (Structured abstract). Database of Abstracts of Reviews of Effectiveness. 2005(3). Rec #: 1279
227 ---. Prevention of nonvertebral fractures by alendronate: a meta-analysis (Structured abstract). Database of Abstracts of Reviews of Effectiveness. 2005(3). Rec #: 1256
228 ---. Treatment of established osteoporosis: a systematic review and cost-utility analysis (Structured abstract). Database of Abstracts of Reviews of Effectiveness. 2005(3). Rec #: 1246
229 Dobnig H. (2004). A review of teriparatide and its clinical efficacy in the treatment of osteoporosis. Expert Opin Pharmacother.
230 Dodidou P, Bruckner T, Hosch S, Haass M, Klar E, Sauer P, Ziegler R, Leidig-Bruckner G. (2003). Better late than never? Experience with intravenous pamidronate treatment in patients with low bone mass or fractures following cardiac or liver transplantation. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
231 Doggrell SA. (2004). Does the combination of alendronate and parathyroid hormone give a greater benefit than either agent alone in osteoporosis?. Expert Opin Pharmacother.
232 Donahue JG, Chan KA, Andrade SE, Beck A, Boles M, Buist DS, Carey VJ, Chandler JM, Chase GA, Ettinger B, Fishman P, Goodman M, Guess HA, Gurwitz JH, LaCroix AZ, Levin TR, Platt R. (2002). Gastric and duodenal safety of daily alendronate. Arch Intern Med.
233 Dougherty JA. (2002). Risedronate for the prevention and treatment of corticosteroid-induced osteoporosis. Ann Pharmacother.
234 Drake, A. J. 3rd; Brietzke, S. A.; Aprill, B. S., and Shakir, K. M. Effect of alendronate treatment on bone mineral density in male patients with osteoporosis. Endocr Pract. 1999 Jul–1999 Aug 31; 5(4):184–90. Rec #: 2060
235 Eastell R, Colwell A, Hampton L, Reeve J. (1997). Biochemical markers of bone resorption compared with estimates of bone resorption from radiotracer kinetic studies in osteoporosis. Journal of Bone and Mineral Research : the Official Journal of the American Society for Bone and Mineral Research.
236 Eastell R, Reid DM, Compston J, Cooper C, Fogelman I, Francis RM, Hay SM, Hosking DJ, Purdie DW, Ralston SH, Reeve J, Russell RG, Stevenson JC. (2001). Secondary prevention of osteoporosis: when should a non-vertebral fracture be a trigger for action?. QJM.
237 Ebeling PR, Russell RG. (2003). Teriparatide (rhPTH 1–34) for the treatment of osteoporosis. Int J Clin Pract.
238 Emkey R, Koltun W, Beusterien K, Seidman L, Kivitz A, Devas V, Masanauskaite D. (2005). Patient preference for once-monthly ibandronate versus once-weekly alendronate in a randomized, open-label, cross-over trial: the Boniva Alendronate Trial in Osteoporosis (BALTO). Curr Med Res Opin.
239 Eriksen EF, Kassem M, Langdahl B. (1996). European and North American Experience with HRT for the prevention of osteoporosis. Bone.
240 Eriksen EF, Robins DA. (2004). Teriparatide: A bone formation treatment for osteoporosis. Drugs Today (Barc).
241 Ettinger B, Pressman A, Schein J. (1998). Clinic visits and hospital admissions for care of acid-related upper gastrointestinal disorders in women using alendronate for osteoporosis. Am J Manag Care.
242 Ettinger B, San Martin J, Crans G, Pavo I. (2004). Differential effects of teriparatide on BMD after treatment with raloxifene or alendronate. J Bone Miner Res.
243 Fadanelli ME, Bone HG. (2004). Combining bisphosphonates with hormone therapy for postmenopausal osteoporosis. Treat Endocrinol.
244 Fairney A, Kyd P, Thomas E, Wilson J. (2000). Response to alendronate in osteoporosis after previous treatment with etidronate. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
245 Fairney A, Kyd P, Thomas E, Wilson J. (1998). The use of cyclical etidronate in osteoporosis: changes after completion of 3 years treatment. Br J Rheumatol.
246 Famularo G, De Simone C. (2001). Fatal esophageal perforation with alendronate. Am J Gastroenterol.
247 Farquhar, C. M.; Marjoribanks, J.; Lethaby, A.; Lamberts, Q., and Suckling, J. A. Long term hormone therapy for perimenopausal and postmenopausal women. Cochrane Database of Systematic Reviews. 2005(3). Rec #: 1137
248 Farrugia MC, Summerlin DJ, Krowiak E, Huntley T, Freeman S, Borrowdale R, Tomich C. (2006). Osteonecrosis of the mandible or maxilla associated with the use of new generation bisphosphonates. Laryngoscope.
249 Fatourechi V, Heath H. (1987). Salmon calcitonin in the treatment of postmenopausal osteoporosis. Ann Intern Med.
250 Fedelesova V, Chylova K, Dzurik. (2000). [Treatment of postmenopausal osteoporosis with raloxifene]. Bratislavske Lekarske Listy.
251 Feinberg AW. (1999). Fewer fractures with raloxifene. Health News.
252 Fentiman IS, Caleffi M, Rodin A, Murby B, Fogelman I. (1989). Bone mineral content of women receiving tamoxifen for mastalgia. Br J Cancer.
253 Fiechtner, J. J. Hip fracture prevention. Drug therapies and lifestyle modifications that can reduce risk. Postgrad Med. 2003 Sep; 114(3):22–8, 32. Rec #: 2226
254 Fink E, Cormier C, Steinmetz P, Kindermans C, Le Bouc Y, Souberbielle JC. (2000). Differences in the capacity of several biochemical bone markers to assess high bone turnover in early menopause and response to alendronate therapy. Osteoporos Int.
255 Finkelstein JS. (2006). Calcium plus vitamin D for postmenopausal women—bone appetit?. N Engl J Med.
256 Fleisch HA. (1997). Bisphosphonates: preclinical aspects and use in osteoporosis. Ann Med.
257 Fogelman, I.; Moreland, L.; Woodson, G., and et al. Gastrointestinal side effects and endoscopic findings similar between risedronate and placebo-treated patients [abstract]. 2000; 11, (Suppl 2): S179 Abstract 459 (423). Rec #: 2963
258 Follin SL, Hansen LB. (2003). Current approaches to the prevention and treatment of postmenopausal osteoporosis. Am J Health Syst Pharm.
259 Fonderico F, Fittipaldi MR, Vitale G, Ciccarelli A, Lupoli GA, Panico A, Cascella T, Lupoli G. (2002). Medical treatment of male osteoporosis. J Endocrinol Invest.
260 Forbes RB, Grant DJ, MacWalter RS. (1995). Cyclical etidronate and calcium carbonate (with citrate) supplementation for osteoporosis unmasking primary hyperparathyroidism. Scott Med J.
261 Fox J. (2002). Developments in parathyroid hormone and related peptides as bone-formation agents. Curr Opin Pharmacol.
262 Francis RM. (1999). The effects of testosterone on osteoporosis in men. Clin Endocrinol (Oxf).
263 Freeman, T. R. Teriparatide: a novel agent that builds new bone. J Am Pharm Assoc (Wash DC). 2003 Jul–2003 Aug 31; 43(4):535–7. Rec #: 2233
264 Friedman MN. (1998). Effects of raloxifene in postmenopausal women. N Engl J Med.
265 Fugazzotto PA, Lightfoot S. (2006). Bisphosphonate associated osteonecrosis of the jaws and endodontic treatment: two case reports. J Mass Dent Soc.
266 Fujita T, Fujii Y, Miyauchi A, Takagi Y. (1999). Comparison of antiresorptive activities of ipriflavone, an isoflavone derivative, and elcatonin, an eel carbocalcitonin. J Bone Miner Metab.
267 Fujita T, Satomura A, Hidaka M, Ohsawa I, Endo M, Ohi H. (2000). Acute alteration in bone mineral density and biochemical markers for bone metabolism in nephrotic patients receiving high-dose glucocorticoid and one-cycle etidronate therapy. Calcif Tissue Int.
268 Fujita T, Fujii Y, Nakamura T, Miyauchi A, Takagi Y. (2000). Effect of avicatonin (chicken carbocalcitonin) on galvanic skin response: a randomized, prospective, double-blind, controlled study for an objective assessment of pain. Calcified Tissue International.
269 Fuller KE. (2004). Effects of parathyroid hormone and alendronate alone or in combination in osteoporosis. N Engl J Med.
270 Gallacher SJ, Fenner JA, Anderson K, Bryden FM, Banham SW, Logue FC, Cowan RA, Boyle IT. (1992). Intravenous pamidronate in the treatment of osteoporosis associated with corticosteroid dependent lung disease: an open pilot study. Thorax.
271 Gamble CL. (1995). Osteoporosis: drug and nondrug therapies for the patient at risk. Geriatrics.
272 Gandrud, L. M.; Cheung, J. C.; Daniels, M. W., and Bachrach, L. K. Low-dose intravenous pamidronate reduces fractures in childhood osteoporosis. J Pediatr Endocrinol Metab. 2003 Jul–2003 Aug 31; 16(6):887–92. Rec #: 2413
273 Gangji V, Appelboom T. (1999). Analgesic effect of intravenous pamidronate on chronic back pain due to osteoporotic vertebral fractures. Clin Rheumatol.
274 Garland CF, Garland FC, Gorham ED. (1991). Can colon cancer incidence and death rates be reduced with calcium and vitamin D?. Am J Clin Nutr.
275 Garnero P, Darte C, Delmas PD. (1999). A model to monitor the efficacy of alendronate treatment in women with osteoporosis using a biochemical marker of bone turnover. Bone.
276 Garnett T, Studd J, Watson N, Savvas M. (1991). A cross-sectional study of the effects of long-term percutaneous hormone replacement therapy on bone density. Obstet Gynecol.
277 Gennari C. (1989). Salmon calcitonin (Miacalcic) nasal spray in prevention and treatment of osteoporosis. Clin Rheumatol.
278 Gennari C, Agnusdei D. (1990). Calcitonin, estrogens and the bone. The Journal of Steroid Biochemistry and Molecular Biology.
279 Gennari C, Camporeale A. (1997). Calcitonin in the treatment of osteoporosis. Osteoporos Int.
280 Geusens P, McClung M. (2001). Review of risedronate in the treatment of osteoporosis. Expert Opin Pharmacother.
281 Geusens P, Vanhoof J, Raus J, Dequeker J, Nijs J, Joly J. (1997). Treatment with etidronate for men with idiopathic osteoporosis. Ann Rheum Dis.
282 Gholz, R. C.; Conde, F., and Rutledge, D. N. Osteoporosis in men treated with androgen suppression therapy for prostate cancer. Clin J Oncol Nurs. 2002 Mar–2002 Apr 30; 6(2):88–93. Rec #: 2734
283 Gloth, F. M. 3rd. Osteoporosis in long term care. Part 2 of 2: treatment strategies. Director. 2004 Autumn; 12(4):234, 237–41. Rec #: 2174
284 Gold DT, Alexander IM, Ettinger MP. (2006). How can osteoporosis patients benefit more from their therapy? Adherence issues with bisphosphonate therapy. Ann Pharmacother.
285 Goodman RL. (2001). The effect of risedronate on the risk of hip fracture in elderly women. N Engl J Med.
286 Gordon, M. S. and Gordon, M. B. Response of bone mineral density to once-weekly administration of risedronate. Endocr Pract. 2002 May–2002 Jun 30; 8(3):202–7. Rec #: 2815
287 Graham DY. (2002). What the gastroenterologist should know about the gastrointestinal safety profiles of bisphosphonates. Dig Dis Sci.
288 Greenblatt D. (2005). Treatment of postmenopausal osteoporosis. Pharmacotherapy.
289 Greenspan SL, Harris ST, Bone H, Miller PD, Orwoll ES, Watts NB, Rosen CJ. (2000). Bisphosphonates: safety and efficacy in the treatment and prevention of osteoporosis. Am Fam Physician.
290 Greenspan SL, Resnick NM. (1993). Fracture risk in woman with osteoporosis: must tennis cease?. JAMA.
291 Greenspan SL, Resnick NM, Parker RA. (2005). Vitamin D supplementation in older women. J Gerontol A Biol Sci Med Sci.
292 Grey A, Cundy T, Reid I. (1994). Continuoius combined oestrogen/progestin therapy is well tolerated and increases bone density at the hip and spine in post-menopausal osteoporosis. Clinical Endocrinology.
293 Grodstein F, Newcomb PA, Stampfer MJ. (1999). Postmenopausal hormone therapy and the risk of colorectal cancer: a review and meta-analysis. Am J Med.
294 Gruber HE, Ivey JL, Baylink DJ, Matthews M, Nelp WB, Sisom K, Chesnut CH. (1984). Long-term calcitonin therapy in postmenopausal osteoporosis. Metabolism.
295 Guanabens N, Peris P, Monegal A, Pons F, Collado A, Munoz-Gomez J. (1994). Lower extremity stress fractures during intermittent cyclical etidronate treatment for osteoporosis. Calcif Tissue Int.
296 Guaraldi G, Ventura P, Albuzza M, Orlando G, Bedini A, Esposito R. (2001). Alendronate treatment for osteoporosis in patients infected with human immunodeficiency virus. Clin Infect Dis.
297 Guay DR. (2005). Ibandronate: a new oral bisphosphonate for postmenopausal osteoporosis. Consult Pharm.
298 ---. Ibandronate, an experimental intravenous bisphosphonate for osteoporosis, bone metastases, and hypercalcemia of malignancy. Pharmacotherapy. 2006 May; 26(5):655–73. Rec #: 3553
299 Guo CY, Thomas WE, al-Dehaimi AW, Assiri AM, Eastell R. (1996). Longitudinal changes in bone mineral density and bone turnover in postmenopausal women with primary hyperparathyroidism. J Clin Endocrinol Metab.
300 Gur A, Denli A, Nas K, Cevik R, Karakoc M, Sarac AJ, Erdogan F. (2002). Possible pathogenetic role of new cytokines in postmenopausal osteoporosis and changes during calcitonin plus calcium therapy. Rheumatol Int.
301 Gutteridge DH. (2004). Alendronate versus calcitriol for prevention of bone loss after cardiac transplantation. N Engl J Med.
302 Gutteridge DH, Retallack RW, Ward LC, Price RI, Stewart GO, Stuckey BG, Prince RL, Kent GN, Bhagat CI, Thompson RI, Nicholson GC. (2003). Bone density changes in Paget's disease 2 years after iv pamidronate: profound, sustained increases in pagetic bone with severity-related loss in forearm nonpagetic cortical bone. Bone.
303 Halbekath J, Becker-Bruser W, Wille H. (2000). Raloxifene and risk of vertebral fracture in postmenopausal women. JAMA.
304 Hamel ME, Sebaldt RJ, Siminoski K, Adachi JD, Papadimitropoulos E, Petrie A, Goldsmith CH. (2005). Influence of fracture history and bone mineral density testing on the treatment of osteoporosis in two non-academic community centers. Osteoporos Int.
305 Hamilton B, McCoy K, Taggart H. (2003). Tolerability and compliance with risedronate in clinical practice. Osteoporos Int.
306 Hanley DA, Ioannidis G, Adachi JD. (2000). Etridronate therapy in the treatment and prevention of osteoporosis. J Clin Densitom.
307 Hansdottir H, Franzson L, Prestwood K, Sigurdsson G. (2004). The effect of raloxifene on markers of bone turnover in older women living in long-term care facilities. J Am Geriatr Soc.
308 Hansen LB, Vondracek SF. (2004). Prevention and treatment of nonpostmenopausal osteoporosis. Am J Health Syst Pharm.
309 Harrington JT, Ste-Marie LG, Brandi ML, Civitelli R, Fardellone P, Grauer A, Barton I, Boonen S. (2004). Risedronate rapidly reduces the risk for nonvertebral fractures in women with postmenopausal osteoporosis. Calcif Tissue Int.
310 Harris ST. (2001). Bisphosphonates for the treatment of postmenopausal osteoporosis: clinical studies of etidronate and alendronate. Osteoporos Int.
311 ---. Risedronate treatment and extended fracture protection in postmenopausal women. Clin Exp Rheumatol. 2001 Nov–2001 Dec 31; 19(6):625–6. Rec #: 2461
312 Hathirat S, Evans MF. (2001). Does raloxifene reduce risk of vertebral fractures? Is this another, brighter way to treat osteoporosis?. Can Fam Physician.
313 Haworth CS, Selby PL, Webb AK, Adams JE, Freemont TJ. (1999). Oral corticosteroids and bone pain after pamidronate in adults with cystic fibrosis. Lancet.
314 Heaney, R. P. Bone mass, bone fragility, and the decision to treat. JAMA. 1998 Dec 23–1998 Dec 30; 280(24):2119–20. Rec #: 1117
315 Heaney RP, Recker RR. (2005). Combination and sequential therapy for osteoporosis. N Engl J Med.
316 Heaney RP, Zizic TM, Fogelman I, Olszynski WP, Geusens P, Kasibhatla C, Alsayed N, Isaia G, Davie MW, Chesnut CH. (2002). Risedronate reduces the risk of first vertebral fracture in osteoporotic women. Osteoporos Int.
317 Hebert-Croteau N. (1998). A meta-analysis of hormone replacement therapy and colon cancer in women. Cancer Epidemiol Biomarkers Prev.
318 Hecker TM, Aris RM. (2004). Management of osteoporosis in adults with cystic fibrosis. Drugs.
319 Heijckmann AC, Juttmann JR, Wolffenbuttel BH. (2002). Intravenous pamidronate compared with oral alendronate for the treatment of postmenopausal osteoporosis. Neth J Med.
320 Heilberg IP, Martini LA, Teixeira SH, Szejnfeld VL, Carvalho AB, Lobao R, Draibe SA. (1998). Effect of etidronate treatment on bone mass of male nephrolithiasis patients with idiopathic hypercalciuria and osteopenia. Nephron.
321 Hemminki E. (2000). Hormone replacement therapy: discrepancies between evidence and recommendations. Scand J Public Health.
322 Hesch RD, Busch U, Prokop M, Delling G, Rittinghaus EF. (1989). Increase of vertebral density by combination therapy with pulsatile 1–38hPTH and sequential addition of calcitonin nasal spray in osteoporotic patients. Calcif Tissue Int.
323 Heyneman CA. (1993). Treatment of postmenopausal osteoporosis with etidronate. Ann Pharmacother.
324 Hill JA, Goldin JG, Gjertson D, Emerick AM, Greaser LD, Yoon HC, Khorrami S, Aziz D, Adams JS. (2002). Progression of coronary artery calcification in patients taking alendronate for osteoporosis. Acad Radiol.
325 Hillner BE, Ingle JN, Chlebowski RT, Gralow J, Yee GC, Janjan NA, Cauley JA, Blumenstein BA, Albain KS, Lipton A, Brown S. (2003). American Society of Clinical Oncology 2003 update on the role of bisphosphonates and bone health issues in women with breast cancer. J Clin Oncol.
326 Hirsch LJ, Pryor-Tillotson S. (1995). An overview of the results of clinical trials with alendronate, a promising treatment of osteoporosis in postmenopausal women. Ann Ital Med Int.
327 Ho YV, Frauman AG, Thomson W, Seeman E. (2000). Effects of alendronate on bone density in men with primary and secondary osteoporosis. Osteoporos Int.
328 Hochberg M. (2000). Preventing fractures in postmenopausal women with osteoporosis. A review of recent controlled trials of antiresorptive agents. Drugs Aging.
329 Hochberg MC. (1997). Bisphosphonates in the treatment of osteoporosis. Rev Rhum Engl Ed.
330 Hochberg MC, Greenspan S, Wasnich RD, Miller P, Thompson DE, Ross PD. (2002). Changes in bone density and turnover explain the reductions in incidence of nonvertebral fractures that occur during treatment with antiresorptive agents. J Clin Endocrinol Metab.
331 Hodgson, S. F.; Watts, N. B.; Bilezikian, J. P.; Clarke, B. L.; Gray, T. K.; Harris, D. W.; Johnston, C. C. Jr; Kleerekoper, M.; Lindsay, R.; Luckey, M. M.; McClung, M. R.; Nankin, H. R.; Petak, S. M.; Recker, R. R.; Anderson, R. J.; Bergman, D. A.; Bloomgarden, Z. T.; Dickey, R. A.; Palumbo, P. J.; Peters, A. L.; Rettinger, H. I.; Rodbard, H. W., and Rubenstein, H. A. American Association of Clinical Endocrinologists medical guidelines for clinical practice for the prevention and treatment of postmenopausal osteoporosis: 2001 edition, with selected updates for 2003. Endocr Pract. 2003 Nov–2003 Dec 31; 9(6):544–64. Rec #: 2213
332 Hodsman A, Adachi J, Olszynski W. (1996). Prevention and management of osteoporosis: consensus statements from the Scientific Advisory Board of the Osteoporosis Society of Canada. 6. Use of bisphosphonates in the treatment of osteoporosis. CMAJ.
333 Hodsman AB. (1989). Effects of cyclical therapy for osteoporosis using an oral regimen of inorganic phosphate and sodium etidronate: a clinical and bone histomorphometric study. Bone Miner.
334 Hodsman AB, Fraher LJ, Ostbye T, Adachi JD, Steer BM. (1993). An evaluation of several biochemical markers for bone formation and resorption in a protocol utilizing cyclical parathyroid hormone and calcitonin therapy for osteoporosis. J Clin Invest.
335 Hodsman AB, Hanley DA, Josse R. (2002). Do bisphosphonates reduce the risk of osteoporotic fractures? An evaluation of the evidence to date. CMAJ.
336 Hodsman, A. B. and Steer, B. M. Early histomorphometric changes in response to parathyroid hormone therapy in osteoporosis: evidence for de novo bone formation on quiescent cancellous surfaces. Bone. 1993 May–1993 Jun 30; 14(3):523–7. Rec #: 2321
337 Homik, J.; Cranney, A.; Shea, B.; Tugwell, P.; Wells, G.; Adachi, J., and Suarez-Almazor, M. Bisphosphonates for steroid induced osteoporosis [Systematic Review]. Cochrane Database of Systematic Reviews. 2006; (2). Rec #: 3239
338 Homik, J.; Cranney, A.; Shea, B.; Tugwell, P.; Wells, G.; Adachi, R., and Suarez-Almazor, M. Bisphosphonates for steroid induced osteoporosis. Cochrane Database of Systematic Reviews. 2005(3). Rec #: 1140
339 Homik JE, Cranney A, Shea B. (1999). A meta-analysis on the use of bisphosphonates in corticosteroid-induced osteoporosis. J Rheumattol.
340 Horwitz M, Stewart A, Greenspan SL. (2000). Sequential parathyroid hormone/alendronate therapy for osteoporosis—robbing Peter to pay Paul?. J Clin Endocrinol Metab.
341 Hosking DJ, Favus M, Yates AJ. (1999). Alendronate in the treatment of postmenopausal osteoporosis. Int J Clin Pract Suppl.
342 Hough S. (2003). New anabolic agents in the treatment of osteoporosis. S Afr Med J.
343 Hough S, Ascott-Evans B, de Villiers T, de Weerd J, Ellis G, Lipschitz S. (2004). Position paper of the National Osteoporosis Foundation of South Africa (NOFSA) on the use of parathyroid hormone (PTH 1–34) in the treatment of osteoporosis. S Afr Med J.
344 Howard M, Burns S, Chu J. (2006). Do calcium and vitamin D supplements prevent fractures?. Can Fam Physician.
345 Hulley SB, Grady D. (2004). The WHI estrogen-alone trial—do things look any better?. JAMA.
346 Hutton SF. (2003). Forteo (teriparatide): first approved medication to rebuild bone. S D J Med.
347 Ikai T, Uematsu M, Eun SS, Kimura C, Hasegawa C, Miyano S. (2001). Prevention of secondary osteoporosis postmenopause in hemiplegia. American Journal of Physical Medicine & Rehabilitation / Association of Academic Physiatrists.
348 Iwamoto J, Takeda T, Ichimura S. (2002). Beneficial effect of etidronate on bone loss after cessation of exercise in postmenopausal osteoporotic women. Am J Phys Med Rehabil.
349 ---. Combined treatment with vitamin k2 and bisphosphonate in postmenopausal women with osteoporosis. Yonsei Med J. 2003 Oct 30; 44(5):751–6. Rec #: 2803
350 Iwamoto J, Takeda T, Sato Y. (2006). Efficacy and safety of alendronate and risedronate for postmenopausal osteoporosis. Curr Med Res Opin.
351 ---. Efficacy of oral etidronate for skeletal diseases in Japan. Yonsei Med J. 2005 Jun 30; 46(3):313–20. Rec #: 2768
352 ---. Prevention and treatment of corticosteroid-induced osteoporosis. Yonsei Med J. 2005; 46(4):456–63. Rec #: 3312
353 Iwamoto J, Takeda T, Sato Y, Uzawa M. (2004). Determinants of one-year response of lumbar bone mineral density to alendronate treatment in elderly Japanese women with osteoporosis. Yonsei Med J.
354 ---. Early changes in urinary cross-linked N-terminal telopeptides of type I collagen level correlate with 1-year response of lumbar bone mineral density to alendronate in postmenopausal Japanese women with osteoporosis. J Bone Miner Metab. 2005; 23(3):238–42. Rec #: 2771
355 ---. Effect of whole-body vibration exercise on lumbar bone mineral density, bone turnover, and chronic back pain in post-menopausal osteoporotic women treated with alendronate. Aging Clin Exp Res. 2005 Apr; 17(2):157–63. Rec #: 2363
356 Jackson JA, Kleerekoper M. (1990). Osteoporosis in men: diagnosis, pathophysiology, and prevention. Medicine (Baltimore).
357 Jarvinen R, Knekt P, Hakulinen T, Aromaa A. (2001). Prospective study on milk products, calcium and cancers of the colon and rectum. Eur J Clin Nutr.
358 Javaid MK, Cooper C. (2001). How to prevent fractures in the individual with osteoporosis. Best Pract Res Clin Rheumatol.
359 Jeal W, Barradell LB, McTavish D. (1997). Alendronate. A review of its pharmacological properties and therapeutic efficacy in postmenopausal osteoporosis. Drugs.
360 Johansen, K. L. Testosterone metabolism and replacement therapy in patients with end-stage renal disease. Semin Dial. 2004 May–2004 Jun 30; 17(3):202–8. Rec #: 2867
361 Johnell, O. Review: vitamin D plus calcium, but not vitamin D alone, prevents osteoporotic fractures in older persons. ACP J Club. 2006 Jan–2006 Feb 28; 144(1):14. Rec #: 3379
362 Jowsey J, Riggs BL, Goldsmith RS, Kelly PJ, Arnaud CD. (1971). Effects of prolonged administration of porcine calcitonin in postmenopausal osteoporosis. J Clin Endocrinol Metab.
363 Jowsey J, Riggs BL, Kelly PJ, Hoffman DL. (1978). Calcium and salmon calcitonin in treatment of osteoporosis. J Clin Endocrinol Metab.
364 Jowsey J, Riggs BL, Kelly PJ, Hoffman DL, Bordier P. (1971). The treatment of osteoporosis with disodium ethane-1, 1-diphosphonate. J Lab Clin Med.
365 Kalidas M, Brown P. (2005). Aromatase inhibitors for the treatment and prevention of breast cancer. Clin Breast Cancer.
366 Kamel HK, Duthie EH. (2002). The underuse of therapy in the secondary prevention of hip fractures. Drugs Aging.
367 Kamel, H. K. and Hajjar, R. R. Osteoporosis for the home care physician. Part 2: Management. J Am Med Dir Assoc. 2004 Jul–2004 Aug 31; 5(4):259–62. Rec #: 2188
368 Kampman E, Goldbohm RA, van den Brandt PA, van 't Veer P. (1994). Fermented dairy products, calcium, and colorectal cancer in The Netherlands Cohort Study. Cancer Res.
369 Kanaji A, Higashi M, Namisato M, Ando K, Nakagawa M, Yato Y, Ichinose H, Sakamaki T, Yamada H. (2005). Trochanteric hip fracture in an elderly patient with leprosy during osteoporosis treatment with risedronate and alfacalcidol. J Bone Miner Metab.
370 Kananen K, Volin L, Tahtela R, Laitinen K, Ruutu T, Valimaki MJ. (2002). Recovery of bone mass and normalization of bone turnover in long-term survivors of allogeneic bone marrow transplantation. Bone Marrow Transplant.
371 Kanis JA. (2002). Calcitonin in osteoporosis. Bone.
372 Kanis JA, Barton IP, Johnell O. (2005). Risedronate decreases fracture risk in patients selected solely on the basis of prior vertebral fracture. Osteoporos Int.
373 Kanis JA, Borgstrom F, Johnell O, Jonsson B. (2004). Cost-effectiveness of risedronate for the treatment of osteoporosis and prevention of fractures in postmenopausal women. Osteoporos Int.
374 Kanis JA, Delmas P, Burckhardt P, Cooper C, Torgerson D. (1997). Guidelines for diagnosis and management of osteoporosis. The European Foundation for Osteoporosis and Bone Disease. Osteoporos Int.
375 Kanis JA, Gertz BJ, Singer F, Ortolani S. (1995). Rationale for the use of alendronate in osteoporosis. Osteoporos Int.
376 Kanis JA, Johansson H, Oden A, De Laet C, Johnell O, Eisman JA, Mc Closkey E, Mellstrom D, Pols H, Reeve J, Silman A, Tenenhouse A. (2005). A meta-analysis of milk intake and fracture risk: low utility for case finding. Osteoporos Int.
377 Kanis JA, Johnell O, Gullberg B, Allander E, Dilsen G, Gennari C, Lopes Vaz AA, Lyritis GP, Mazzuoli G, Miravet L, et al. (1992). Evidence for efficacy of drugs affecting bone metabolism in preventing hip fracture. BMJ.
378 Kapetanakis EI, Antonopoulos AS, Antoniou TA, Theodoraki KA, Zarkalis DA, Sfirakis PD, Chilidou DA, Alivizatos PA. (2005). Effect of long-term calcitonin administration on steroid-induced osteoporosis after cardiac transplantation. J Heart Lung Transplant.
379 Karachalios T, Lyritis GP, Kaloudis J, Roidis N, Katsiri M. (2004). The effects of calcitonin on acute bone loss after pertrochanteric fractures. A prospective, randomised trial. The Journal of Bone and Joint Surgery British Volume.
380 Katznelson L, Finkelstein JS, Schoenfeld DA, Rosenthal DI, Anderson EJ, Klibanski A. (1996). Increase in bone density and lean body mass during testosterone administration in men with acquired hypogonadism. J Clin Endocrinol Metab.
381 Kaye PS. (1999). Gastric hemorrhage and ulceration in hiatal hernia sac associated with alendronate. Dig Dis Sci.
382 Keen RW, Spector TD. (1996). Alendronate: a new bisphosphonate for the treatment of osteoporosis. Br J Clin Pract.
383 Kendler D, Khan AA. (1998). Re: Use of cyclic etidronate and the prevention of non-vertebral fractures. Br J Rheumatol.
384 Kessenich CR. (2003). PTH revisited for osteoporosis treatment. Nurse Pract.
385 Khan SA, Kanis JA, Vasikaran S, Kline WF, Matuszewski BK, McCloskey EV, Beneton MN, Gertz BJ, Sciberras DG, Holland SD, Orgee J, Coombes GM, Rogers SR, Porras AG. (1997). Elimination and biochemical responses to intravenous alendronate in postmenopausal osteoporosis. J Bone Miner Res.
386 Kherani RB, Papaioannou A, Adachi JD. (2002). Long-term tolerability of the bisphosphonates in postmenopausal osteoporosis: a comparative review. Drug Saf.
387 Khosla S. (2003). Parathyroid hormone plus alendronate—a combination that does not add up. N Engl J Med.
388 Khovidhunkit W, Shoback DM. (1999). Clinical effects of raloxifene hydrochloride in women. Ann Intern Med.
389 Kiel DP, Felson DT, Anderson JJ, Wilson PW, Moskowitz MA. (1987). Hip fracture and the use of estrogens in postmenopausal women. The Framingham Study. N Engl J Med.
390 Kirby M. (1998). Tolerability of alendronate. Comparison group taking placebo should have been included. BMJ.
391 Kirk D, Fish SA. (2004). Medical management of osteoporosis. Am J Manag Care.
392 Kirk JK, Spangler JG. (1996). Alendronate: a bisphosphonate for treatment of osteoporosis. Am Fam Physician.
393 Klovning A, Norheim OF. (1999). Alendronate and fracture prevention. JAMA.
394 Koch CA. (2001). Rapid increase in bone mineral density in a child with osteoporosis and autoimmune hypoparathyroidism treated with PTH 1–34. Exp Clin Endocrinol Diabetes.
395 Kollerup G, Sorensen HA, Hyldstrup L, Storm T. (1997). Assessment of different markers of bone resorption in postmenopausal osteoporotic women treated with pamidronate. Scandinavian Journal of Clinical and Laboratory Investigation.
396 Koster JC, Hackeng WH, Mulder H. (1996). Diminished effect of etidronate in vitamin D deficient osteopenic postmenopausal women. Eur J Clin Pharmacol.
397 Kovac, D.; Lindic, J.; Kandus, A., and Bren, A. F. Prevention of bone loss in kidney graft recipients. Transplant Proc. 2001 Feb–2001 Mar 31; 33(1–2):1144–5. Rec #: 2827
398 ---. Prevention of bone loss with alendronate in kidney transplant recipients. Transplantation. 2000 Nov 27; 70(10):1542–3. Rec #: 2829
399 Krege JH, Donley DW, Marcus R. (2005). Teriparatide, osteoporosis, calcium, and vitamin D. N Engl J Med.
400 Krieg MA, Seydoux C, Sandini L, Goy JJ, Berguer DG, Thiebaud D, Burckhardt P. (2001). Intravenous pamidronate as treatment for osteoporosis after heart transplantation: a prospective study. Osteoporos Int.
401 Kubler A, Schulz G, Cordes U, Beyer J, Krause U. (1992). The influence of testosterone substitution on bone mineral density in patients with Klinefelter's syndrome. Exp Clin Endocrinol.
402 Kudachadkar, R. and O'Regan, R. M. Aromatase inhibitors as adjuvant therapy for postmenopausal patients with early stage breast cancer. CA Cancer J Clin. 2005 May–2005 Jun 30; 55(3):145–63. Rec #: 2840
403 Kuehn BM. (2005). Longer-lasting osteoporosis drugs sought. JAMA.
404 Kumar R. (2001). Glucocorticoid-induced osteoporosis. Curr Opin Nephrol Hypertens.
405 Kupecz D. (1998). Raloxifene: a new class of anti-estrogens for the prevention of osteoporosis. Nurse Pract.
406 Kurland ES, Heller SL, Diamond B, McMahon DJ, Cosman F, Bilezikian JP. (2004). The importance of bisphosphonate therapy in maintaining bone mass in men after therapy with teriparatide. Osteoporos Int.
407 Lamy O, Sandini L, Pache I, Fatio S, Burnand J, Burckhardt P. (2003). Intravenous ibandronate in men with osteoporosis: an open pilot study over 2 years. J Endocrinol Invest.
408 Lanciani, P.; Porzio, V., and Cattani, D. Use of calcitonin in 20 patients suffering from postmenopausal osteoporosis. A proposal for a therapeutical scheme. Panminerva Med. 1991 Apr–1991 Jun 30; 33(2):119–20. Rec #: 2693
409 Landman JO, Papapoulos SE. (1995). Uninterrupted oral bisphosphonate (pamidronate) therapy of patients with osteoporosis is not associated with chronic stimulation of parathyroid hormone secretion. Osteoporos Int.
410 Landman JO, Schweitzer DH, Frolich M, Hamdy NA, Papapoulos SE. (1995). Recovery of serum calcium concentrations following acute hypocalcemia in patients with osteoporosis on long-term oral therapy with the bisphosphonate pamidronate. J Clin Endocrinol Metab.
411 Lane NE. (2004). Parathyroid hormone: evolving therapeutic concepts. Curr Opin Rheumatol.
412 ---. An update on glucocorticoid-induced osteoporosis. Rheum Dis Clin North Am. 2001 Feb; 27(1):235–53. Rec #: 2289
413 Lane NE, Rehman Q. (2000). Parathyroid hormone treatment for glucocorticoid-induced osteoporosis. Clinical and Experimental Rheumatology.
414 Layton D, Clarke A, Wilton LV, Shakir SA. (2005). Safety profile of raloxifene as used in general practice in England: results of a prescription-event monitoring study. Osteoporos Int.
415 Lecart MP, Bruyere O, Reginster JY. (2004). Combination/sequential therapy in osteoporosis. Curr Osteoporos Rep.
416 Leder BZ, Smith MR, Fallon MA, Lee ML, Finkelstein JS. (2001). Effects of gonadal steroid suppression on skeletal sensitivity to parathyroid hormone in men. The Journal of Clinical Endocrinology and Metabolism.
417 Lee, V. K. and McCarthy, M. W. Drug therapy for osteoporosis management in nursing home residents. Lippincotts Prim Care Pract. 1999 Mar–1999 Apr 30; 3(2):150–62. Rec #: 2653
418 Leggate J, Farish E, Fletcher CD, McIntosh W, Hart DM, Sommerville JM. (1984). Calcitonin and postmenopausal osteoporosis. Clin Endocrinol (Oxf).
419 Leifke E, Korner HC, Link TM, Behre HM, Peters PE, Nieschlag E. (1998). Effects of testosterone replacement therapy on cortical and trabecular bone mineral density, vertebral body area and paraspinal muscle area in hypogonadal men. Eur J Endocrinol.
420 Leite AF, Figueiredo PT, Melo NS, Acevedo AC, Cavalcanti MG, Paula LM, Paula AP, Guerra EN. (2006). Bisphosphonate-associated osteonecrosis of the jaws. Report of a case and literature review. Oral Surg Oral Med Oral Pathol Oral Radiol Endod.
421 Levis S, Quandt SA, Thompson D, Scott J, Schneider DL, Ross PD, Black D, Suryawanshi S, Hochberg M, Yates J. (2002). Alendronate reduces the risk of multiple symptomatic fractures: results from the fracture intervention trial. Journal of the American Geriatrics Society.
422 Li I. (2000). Does alendronate treatment prevent vertebral fractures in men with osteoporosis?. The Journal of Family Practice.
423 Liberman, U. A.; Hochberg, M. C.; Geusens, P.; Shah, A.; Lin, J.; Chattopadhyay, A., and Ross, P. D. Hip and non-spine fracture risk reductions differ among antiresorptive agents: evidence from randomised controlled trials. Int J Clin Pract. 2006 Oct 4. Rec #: 3544
424 Liberman UA, Weiss SR, Broll J, Minne HW, Quan H, Bell NH, Rodriguez-Portales J, Downs RW, Dequeker J, Favus M. (1995). Effect of oral alendronate on bone mineral density and the incidence of fractures in postmenopausal osteoporosis. The Alendronate Phase III Osteoporosis Treatment Study Group. N Engl J Med.
425 Liberman UI, Hirsch LJ. (1996). Esophagitis and alendronate. The New England Journal of Medicine.
426 Licata AA. (2005). Osteoporosis, teriparatide, and dosing of calcium and vitamin D. N Engl J Med.
427 Licata AA, Ciaccia AV, Wong M, Draper MW. (2000). Raloxifene: a new choice for treating and preventing osteoporosis. Cleve Clin J Med.
428 Liedholm H, Linne AB. (1996). Alendronate in postmenopausal osteoporosis. N Engl J Med.
429 Lindsay R. (2004). Bone loss after cardiac transplantation. N Engl J Med.
430 ---. Estrogens in prevention and treatment of osteoporosis. Schweiz Med Wochenschr. 1989 Dec 16; 119(50):1806–10. Rec #: 2699
431 Lindsay R, Hart DM, Aitken JM, MacDonald EB, Anderson JB, Clarke AC. (1976). Long-term prevention of postmenopausal osteoporosis by oestrogen. Evidence for an increased bone mass after delayed onset of oestrogen treatment. Lancet.
432 Lindsay R, Hart DM, Forrest C, Baird C. (1980). Prevention of spinal osteoporosis in oophorectomised women. Lancet.
433 Lindsay R, Nieves J, Henneman E, Shen V, Cosman F. (1993). Subcutaneous administration of the amino-terminal fragment of human parathyroid hormone-(1–34): kinetics and biochemical response in estrogenized osteoporotic patients. J Clin Endocrinol Metab.
434 Lindsay, R. ; Scheele, W. H.; Clansey, A. D. J. L.; Hossain, A., and Mitlak, B. H. Reduction in non-vertebral fragility fractures and increase in spinal bone density is maintained 31 months after discontinuation of recombinant human parathyroid hormone (1–34) in post-menopausal women with osteoporosis. Endocrine Society. 113. Rec #: 3083
435 Lindsay R, Scheele WH, Neer R, Pohl G, Adami S, Mautalen C, Reginster JY, Stepan JJ, Myers SL, Mitlak BH. (2004). Sustained vertebral fracture risk reduction after withdrawal of teriparatide in postmenopausal women with osteoporosis. Arch Intern Med.
436 Lippuner K. (2003). Medical treatment of vertebral osteoporosis. Eur Spine J.
437 Loddenkemper, K.; Grauer, A.; Burmester, G. R., and Buttgereit, F. Calcium, vitamin D and etidronate for the prevention and treatment of corticosteroid-induced osteoporosis in patients with rheumatic diseases. Clin Exp Rheumatol. 2003 Jan–2003 Feb 28; 21(1):19–26. Rec #: 2425
438 Loeliger EA. (1995). Four-year study of intermittent cyclic etidronate treatment of postmenopausal osteoporosis. Am J Med.
439 Love RR, Barden HS, Mazess RB, Epstein S, Chappell RJ. (1994). Effect of tamoxifen on lumbar spine bone mineral density in postmenopausal women after 5 years. Arch Intern Med.
440 Lufkin EG, Sarkar S, Kulkarni PM, Ciaccia AV, Siddhanti S, Stock J, Plouffe L. (2004). Antiresorptive treatment of postmenopausal osteoporosis: review of randomized clinical studies and rationale for the Evista alendronate comparison (EVA) trial. Curr Med Res Opin.
441 Lufkin EG, Whitaker MD, Nickelsen T, Arqueta R, Caplan RH, Knickerbocker RK, et al. (1998). Raloxifene effects on bone mineral density and safety asessments in postmenopausal women with osteoporosis [abstract]. Osteoporosis Int.
442 Lukert BP. (1995). Etidronate in the management of glucocorticoid-induced osteoporosis. Am J Med.
443 Lukert BP, Johnson BE, Robinson RG. (1992). Estrogen and progesterone replacement therapy reduces glucocorticoid-induced bone loss. J Bone Miner Res.
444 Lupoli G, Nuzzo V, Di Carlo C, Affinito P, Vollery M, Vitale G, Cascone E, Arlotta F, Nappi C. (1996). Effects of alendronate on bone loss in pre- and postmenopausal hyperthyroid women treated with methimazole. Gynecol Endocrinol.
445 Macedo G, Azevedo F, Ribeiro T. (2001). Ulcerative esophagitis caused by etidronate. Gastrointest Endosc.
446 Macedo JM, Macedo CR, Elkis H, De Oliveira IR. (1998). Meta-analysis about efficacy of anti-resorptive drugs in post-menopausal osteoporosis. J Clin Pharm Ther.
447 Mackay F, Mann RD. (1998). Tolerability of alendronate. Figures given in letter were prevalences, not incidences. BMJ.
448 Mackay FJ, Wilton LV, Pearce GL, Freemantle SN, Mann RD. (1998). United Kingdom experience with alendronate and oesophageal reactions. Br J Gen Pract.
449 Mackey JR, Joy AA. (2005). Skeletal health in postmenopausal survivors of early breast cancer. Int J Cancer.
450 Maconi G, Bianchi Porro G. (1995). Multiple ulcerative esophagitis caused by alendronate. Am J Gastroenterol.
451 Maravic M, Landais P. (2004). Ibandronate and prevention of postmenopausal osteoporosis. Ann Rheum Dis.
452 Marcus R. (2002). Post-menopausal osteoporosis. Best Pract Res Clin Obstet Gynaecol.
453 Maricic M, Gluck O. (2002). Review of raloxifene and its clinical applications in osteoporosis. Expert Opin Pharmacother.
454 Martens MG. (2003). Risk of fracture and treatment to prevent osteoporosis-related fracture in postmenopausal women. A review. J Reprod Med.
455 Marx RE. (2003). Pamidronate (Aredia) and zoledronate (Zometa) induced avascular necrosis of the jaws: a growing epidemic. J Oral Maxillofac Surg.
456 Masaryk P, Lunt M, Benevolenskaya L, Cannata J, Dequeker J, Dohenhof C, Falch JA, Felsenberg D, Pols HA, Poor G, Reid DM, Scheidt-Nave C, Weber K, O'Neill T, Silman AJ, Reeve J. (1998). Effects of menstrual history and use of medications on bone mineral density: the EVOS Study. Calcif Tissue Int.
457 Masud T, Giannini S. (2003). Preventing osteoporotic fractures with bisphosphonates: a review of the efficacy and tolerability. Aging Clin Exp Res.
458 Maughan KL. (1997). Preventing osteoporotic fractures with alendronate. J Fam Pract.
459 McCarus DC. (2006). Fracture prevention in postmenopausal osteoporosis: a review of treatment options. Obstet Gynecol Surv.
460 McClung, B. and McClung, M. Pharmacologic therapy for the treatment and prevention of osteoporosis. Nurs Clin North Am. 2001 Sep; 36(3):433–40, viii. Rec #: 2464
461 McClung M. (2004). Parathyroid hormone for the treatment of osteoporosis. Obstet Gynecol Surv.
462 ---. Use of highly potent bisphosphonates in the treatment of osteoporosis. Curr Osteoporos Rep. 2003 Dec; 1(3):116–22. Rec #: 2361
463 McClung MR. (1996). Current bone mineral density data on bisphosphonates in postmenopausal osteoporosis. Bone.
464 ---. How does raloxifene reduce fracture risk? Menopause. 2002 Sep–2002 Oct 31; 9(5):306–8. Rec #: 2595
465 McCullough ML, Rodriguez C, Diver WR, Feigelson HS, Stevens VL, Thun MJ, Calle EE. (2005). Dairy, calcium, and vitamin D intake and postmenopausal breast cancer risk in the Cancer Preventino Study II Nutrition Cohort. Cancer Epidemiol Biomarkers Prev.
466 McGrath H. (1996). Alendronate in postmenopausal osteoporosis. N Engl J Med.
467 McIlwain HH. (2003). Glucocorticoid-induced osteoporosis: pathogenesis, diagnosis, and management. Prev Med.
468 Medras M, Jankowska EA, Rogucka E. (2001). Effects of long-term testosterone substitutive therapy on bone mineral content in men with hypergonadotrophic hypogonadism. Andrologia.
469 Meier C, Liu PY, Ly LP, de Winter-Modzelewski J, Jimenez M, Handelsman DJ, Seibel MJ. (2004). Recombinant human chorionic gonadotropin but not dihydrotestosterone alone stimulates osteoblastic collagen synthesis in older men with partial age-related androgen deficiency. J Clin Endocrinol Metab.
470 Meier CA. (1998). Role of novel antiresorptive agents for the prevention and treatment of osteoporosis. Eur J Endocrinol.
471 Meunier PJ. (2001). Anabolic agents for treating postmenopausal osteoporosis. Joint Bone Spine.
472 ---. Evidence-based medicine and osteoporosis: a comparison of fracture risk reduction data from osteoporosis randomised clinical trials. Int J Clin Pract. 1999 Mar; 53(2):122–9. Rec #: 2307
473 Miki T, Nakatsuka K, Naka H, Masaki H, Imanishi Y, Ito M, Inaba M, Morii H, Nishizawa Y. (2004). Effect and safety of intermittent weekly administration of human parathyroid hormone 1–34 in patients with primary osteoporosis evaluated by histomorphometry and microstructural analysis of iliac trabecular bone before and after 1 year of treatment. J Bone Miner Metab.
474 Miller, E. and Kalin, M. F. A review of combination regimens for osteoporosis—prevention and treatment. Int J Fertil Womens Med. 2002 Sep–2002 Oct 31; 47(5):198–204. Rec #: 2257
475 Miller KK, Grieco KA, Mulder J, Grinspoon S, Mickley D, Yehezkel R, Herzog DB, Klibanski A. (2004). Effects of risedronate on bone density in anorexia nervosa. The Journal of Clinical Endocrinology and Metabolism.
476 Miller PD. (2004). Effects of parathyroid hormone and alendronate alone or in combination in osteoporosis. N Engl J Med.
477 Miller, P. D.; Bilezikian, J. P.; Deal, C.; Harris, S. T., and Ci, R. P. Clinical use of teriparatide in the real world: initial insights. Endocr Pract. 2004 Mar–2004 Apr 30; 10(2):139–48. Rec #: 2185
478 Millonig G, Graziadei IW, Eichler D, Pfeiffer KP, Finkenstedt G, Muehllechner P, Koenigsrainer A, Margreiter R, Vogel W. (2005). Alendronate in combination with calcium and vitamin D prevents bone loss after orthotopic liver transplantation: a prospective single-center study. Liver Transpl.
479 Misof BM, Roschger P, Cosman F, Kurland ES, Tesch W, Messmer P, Dempster DW, Nieves J, Shane E, Fratzl P, Klaushofer K, Bilezikian J, Lindsay R. (2003). Effects of intermittent parathyroid hormone administration on bone mineralization density in iliac crest biopsies from patients with osteoporosis: a paired study before and after treatment. J Clin Endocrinol Metab.
480 Mitlak BH. (2002). Parathyroid hormone as a therapeutic agent. Curr Opin Pharmacol.
481 Mitterbauer, C.; Schwarz, C.; Haas, M., and Oberbauer, R. Effects of bisphosphonates on bone loss in the first year after renal transplantation—a meta-analysis of randomized controlled trials. Nephrol Dial Transplant. 2006. Rec #: 3274
482 Morgan SL. (2001). Calcium and vitamin D in osteoporosis. Rheum Dis Clin North Am.
483 Morishige K, Yamamoto T, Sawada K, Ohmichi M, Tasaka K, Murata Y. (2003). Etidronate and hormone replacement therapy (HRT) for postmenopausal women with osteoporosis despite HRT. Arch Gynecol Obstet.
484 Morley P, Whitfield JF, Willick GE. (1999). Design and applications of parathyroid hormone analogues. Curr Med Chem.
485 Mulder H, Struys A. (1994). Intermittent cyclical etidronate in the prevention of corticosteroid-induced bone loss. Br J Rheumatol.
486 Munoz-Torres M, Alonso G, Raya MP. (2004). Calcitonin therapy in osteoporosis. Treat Endocrinol.
487 Nakatsuka K, Miki T, Naka H, Inaba M, Nishizawa Y. (2004). Long-term effect of intermittent cyclical etidronate on microarchitecture and quality of trabecular bone in an elderly woman with severe osteoporosis. J Bone Miner Metab.
488 Nardo F, Scrofani V, Costa G, Bellanca S, Petrovec MM, Clemenza F, Licciardello S. (1994). [Therapeutic protocols compared in the treatment of postmenopausal osteoporotic disease]. Minerva Ginecologica.
489 Neer M, Slovik DM, Daly M, Potts T, Nussbaum SR. (1993). Treatment of postmenopausal osteoporosis with daily parathyroid hormone plus calcitriol. Osteoporos Int.
490 Nelson, H. ; Nygren, P.; Freeman, M., and Benjamin, K. Drug class review on estrogens. 2004 Jul http://www.ohsu.edu/drugeffectiveness/reports/documents/Estrogens_Final_Report_u2.pdf. Rec #: 3208
491 Nelson HD, Humphrey LL, Nygren P, Teutsch SM, Allan JD. (2002). Postmenopausal hormone replacement therapy: scientific review. JAMA.
492 Nevitt MC, Chen P, Dore RK, Reginster JY, Kiel DP, Zanchetta JR, Glass EV, Krege JH. (2006). Reduced risk of back pain following teriparatide treatment: a meta-analysis. Osteoporos Int.
493 Newcomb PA, Solomon C, White E. (1999). Tamoxifen and risk of large bowel cancer in women with breast cancer. Breast Cancer Res Treat.
494 Nielsen NM, von der Recke P, Hansen MA, Overgaard K, Christiansen C. (1994). Estimation of the effect of salmon calcitonin in established osteoporosis by biochemical bone markers. Calcif Tissue Int.
495 NIH Consensus Development Panel on Osteoporosis Prevention, Diagnosis and Theapy. (2001). Osteoporosis prevention, diagnosis, and therapy. JAMA.
496 Noguera, A.; Ros, J. B.; Pavia, C.; Alcover, E.; Valls, C.; Villaronga, M., and Gonzalez, E. Bisphosphonates, a new treatment for glucocorticoid-induced osteoporosis in children. J Pediatr Endocrinol Metab. 2003 Apr–2003 May 31; 16(4):529–36. Rec #: 2420
497 Notelovitz M, Johnston M, Smith S, Kitchens C. (1987). Metabolic and hormonal effects of 25-mg and 50-mg 17 beta-estradiol implants in surgically menopausal women. Obstet Gynecol.
498 O'Mahony D. (1999). Prevention of corticosteroid-induced osteoporosis and fractures. J Clin Pharm Ther.
499 O'Neill S, MacLennan A, Bass S, Diamond T, Ebeling P, Findlay D, Flicker L, Markwell A, Nowson C, Pocock N, Sambrook P, Singh MF. (2004). Guidelines for the management of postmenopausal osteoporosis for GPs. Aust Fam Physician.
500 Odell WD. (1996). Testosterone treatment of men treated with glucocorticoids. Arch Intern Med.
501 Olszynski WP, Shawn Davison K, Adachi JD, Brown JP, Cummings SR, Hanley DA, Harris SP, Hodsman AB, Kendler D, McClung MR, Miller PD, Yuen CK. (2004). Osteoporosis in men: epidemiology, diagnosis, prevention, and treatment. Clin Ther.
502 Orme SM, Simpson M, Stewart SP, Oldroyd B, Westmacott CF, Smith MA, Belchetz PE. (1994). Comparison of changes in bone mineral in idiopathic and secondary osteoporosis following therapy with cyclical disodium etidronate and high dose calcium supplementation. Clin Endocrinol (Oxf).
503 Ortego-Centeno N, Munoz-Torres M, Callejas-Rubio JL, Riera-Montes M. (2005). Etidronate and glucocorticoid induced osteoporosis. J Rheumatol.
504 Orwoll ES. (2004). Treatment of osteoporosis in men. Calcif Tissue Int.
505 Ott SM. (1993). Clinical effects of bisphosphonates in involutional osteoporosis. J Bone Miner Res.
506 ---. Fractures after long-term alendronate therapy. J Clin Endocrinol Metab. 2001 Apr; 86(4):1835–6. Rec #: 2470
507 ---. Ten years of alendronate treatment for osteoporosis in postmenopausal women. N Engl J Med. 2004 Jul 8; 351(2):190–2; author reply 190–2. Rec #: 2784
508 Overgaard K, Hansen MA, Dirksen KL, Christiansen C. (1992). Rectal salmon calcitonin for the treatment of postmenopausal osteoporosis. Calcif Tissue Int.
509 Overgaard K, Hansen MA, Nielsen VA, Riis BJ, Christiansen C. (1990). Discontinuous calcitonin treatment of established osteoporosis—effects of withdrawal of treatment. The American Journal of Medicine.
510 Ozdemir F, Rodoplu M. (2005). Benefit period using alendronate to increase bone mineral density in women with osteoporosis?. Chin Med J (Engl).
511 Ozoran, K.; Paker, N.; Basgoze, O.; Hascelik, Z.; Erzen, C.; Narman, S., and Ozker, R. Calcitonin and calcium combined therapy in osteoporosis: effects on vertebra trabecular bone density. J Int Med Res. 1989 Jul–1989 Aug 31; 17(4):395–400. Rec #: 2702
512 Palmer, S. C.; McGregor, D. O., and Strippoli, G. F. M. Interventions for preventing bone disease in kidney transplant recipients. Cochrane Database of Systematic Reviews. 2005(3). Rec #: 1132
513 Palmer SC, Strippoli GF, McGregor DO. (2005). Interventions for preventing bone disease in kidney transplant recipients: a systematic review of randomized controlled trials. Am J Kidney Dis.
514 Palomba S, Numis FG, Mossetti G, Rendina D, Vuotto P, Russo T, Zullo F, Nappi C, Nunziata V. (2003). Raloxifene administration in post-menopausal women with osteoporosis: effect of different BsmI vitamin D receptor genotypes. Hum Reprod.
515 Palomba S, Numis FG, Mossetti G, Rendina D, Vuotto P, Russo T, Zullo F, Nappi C, Nunziata V. (2003). Effectiveness of alendronate treatment in postmenopausal women with osteoporosis: relationship with BsmI vitamin D receptor genotypes. Clinical Endocrinology.
516 Papadaki HA, Tsatsanis C, Christoforidou A, Malliaraki N, Psyllaki M, Pontikoglou C, Miliaki M, Margioris AN, Eliopoulos GD. (2004). Alendronate reduces serum TNFalpha and IL-1beta, increases neutrophil counts, and improves bone mineral density and bone metabolism indices in patients with chronic idiopathic neutropenia (CIN)-associated osteopenia/osteoporosis. Journal of Bone and Mineral Metabolism.
517 Papapoulos SE. (2000). Bisphosphonates in the treatment of osteoporosis. Principles and efficacy. Ann Med Interne (Paris).
518 ---. Ibandronate: a potent new bisphosphonate in the management of postmenopausal osteoporosis. Int J Clin Pract. 2003 Jun; 57(5):417–22. Rec #: 3408
519 Park L, Evans MF. (1999). Raloxifene: designer estrogen for preventing postmenopausal osteoporosis. Can Fam Physician.
520 Parker CR, Blackwell PJ, Fairbairn KJ, Hosking DJ. (2002). Alendronate in the treatment of primary hyperparathyroid-related osteoporosis: a 2-year study. J Clin Endocrinol Metab.
521 Patlak M. (2001). Bone builders: the discoveries behind preventing and treating osteoporosis. FASEB J.
522 Peichl P, Marteau R, Griesmacher A, Kumpan W, Schedl R, Prosquil E, Fasol P, Broll H. (2005). Salmon calcitonin nasal spray treatment for postmenopausal women after hip fracture with total hip arthroplasty. J Bone Miner Metab.
523 Penning-van Beest FJ, Goettsch WG, Erkens JA, Herings RM. (2006). Determinants of persistence with bisphosphonates: a study in women with postmenopausal osteoporosis. Clin Ther.
524 Peretz A, Body JJ, Dumon JC, Rozenberg S, Hotimski A, Praet JP, Moris M, Ham H, Bergmann P. (1996). Cyclical pamidronate infusions in postmenopausal osteoporosis. Maturitas.
525 Perez Cano R, Moruno R, Montoya MJ, Vazquez MA, Galan F, Garrido M. (1989). ADFR therapy in the prevention of bone loss after menopause. Clin Rheumatol.
526 Perez-Lopez FR. (2004). Postmenopausal osteoporosis and alendronate. Maturitas.
527 Perifanis V, Vyzantiadis T, Vakalopoulou S, Tziomalos K, Garypidou V, Athanassiou-Metaxa M, Harsoulis F. (2004). Treatment of beta-thalassaemia-associated osteoporosis with zoledronic acid. Br J Haematol.
528 Peters ML, Leonard M, Licata AA. (2001). Role of alendronate and risedronate in preventing and treating osteoporosis. Cleve Clin J Med.
529 Pines A, Eckstein N, Kopernik G, Ayalon D, Comaneshter D, Frenkel Y. (2003). Month 3 and month 6 measurements of bone mineral density predict the annual outcome in postmenopausal women with osteoporosis in whom alendronate was added to long-term HRT. Maturitas.
530 Pitts WR. (2003). Re: randomized controlled trial of zoledronic acid to prevent bone loss in men receiving androgen deprivation therapy for nonmetastatic prostate cancer. Journal of Urology.
531 Plotkin H, Gundberg C, Mitnick M, Stewart AF. (1998). Dissociation of bone formation from resorption during 2-week treatment with human parathyroid hormone-related peptide-(1–36) in humans: potential as an anabolic therapy for osteoporosis. J Clin Endocrinol Metab.
532 Pontiroli AE, Pajetta E, Calderara A, Alberetto M, Pozza G, Manganelli V, Resmini G, Tessari L, Maresca V. (1991). Intranasal and intramuscular human calcitonin in female osteoporosis and in Paget's disease of bones: a pilot study. J Endocrinol Invest.
533 Posaci C, Altunyurt S, Islekel H, Saygili U, Altekin E, Onvural A, Onvural B. (2002). The values of urinary NTx in postmenopausal women undergoing HRT; the role of additional alendronate therapy. Maturitas.
534 Prelevic GM. (2001). Osteoporosis in men. J R Soc Med.
535 Prelevic GM, Adashi EY. (1992). Postmenopausal osteoporosis: prevention and treatment with calcitonin. Gynecol Endocrinol.
536 Prostko M. (1997). Meta-analysis of prevention of nonvertebral fractures by alendronate. JAMA.
537 Quattrocchi E, Kourlas H. (2004). Teriparatide: a review. Clin Ther.
538 Ragsdale, A. B.; Barringer, T. A. 3rd, and Anastasio, G. D. Alendronate treatment to prevent osteoporotic fractures. Arch Fam Med. 1998 Nov–1998 Dec 31; 7(6):583–6. Rec #: 2500
539 Raisz L, Smith JA, Trahiotis M, Fall P, Shoukri K, Digennaro J, Sacco-Gibson N. (2000). Short-term risedronate treatment in postmenopausal women: effects on biochemical markers of bone turnover. Osteoporos Int.
540 Ramaswamy B, Shapiro CL. (2003). Osteopenia and osteoporosis in women with breast cancer. Semin Oncol.
541 Ravn P. (2002). Bisphosphonates for prevention of postmenopausal osteoporosis. Dan Med Bull.
542 Ravn P, Alexandersen P, Mollgaard A. (1999). Bone densitometry: a new, highly responsive region of interest in the distal forearm to monitor the effect of osteoporosis treatment. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
543 Reeve J, Arlot M, Bernat M, Charhon S, Edouard C, Slovik D, Vismans FJ, Meunier PJ. (1981). Calcium-47 kinetic measurements of bone turnover compared to bone histomorphometry in osteoporosis: the influence of human parathyroid fragment (hPTH 1–34) therapy. Metab Bone Dis Relat Res.
544 Reeve J, Arlot M, Price TR, Edouard C, Hesp R, Hulme P, Ashby JP, Zanelli JM, Green JR, Tellez M, et al. (1987). Periodic courses of human 1–34 parathyroid peptide alternating with calcitriol paradoxically reduce bone remodelling in spinal osteoporosis. Eur J Clin Invest.
545 Reeve J, Arlot ME, Bradbeer JN, Hesp R, Mcally E, Meunier PJ, Zanelli JM. (1993). Human parathyroid peptide treatment of vertebral osteoporosis. Osteoporos Int.
546 Reeve J, Bradbeer JN, Arlot M, Davies UM, Green JR, Hampton L, Edouard C, Hesp R, Hulme P, Ashby JP, et al. (1991). hPTH 1–34 treatment of osteoporosis with added hormone replacement therapy: biochemical, kinetic and histological responses. Osteoporos Int.
547 Reeve J, Hesp R, Williams D, Hulme P, Klenerman L, Zanelli JM, Darby AJ, Tregear GW, Parsons JA. (1976). Anabolic effect of low doses of a fragment of human parathyroid hormone on the skeleton in postmenopausal osteoporosis. Lancet.
548 Reeve J, Tregear GW, Parsons JA. (1976). Priliminary trial of low doses of human parathyroid hormone 1–34 peptide in treatment of osteoporosis. Calcif Tissue Res.
549 Reginster, J. Y. Risedronate increases bone mineral density and reduces the vertebral fracture incidence in postmenopausal women. Clin Exp Rheumatol. 2001 Mar–2001 Apr 30; 19(2):121–2. Rec #: 2468
550 Reginster, J. Y.; Deroisy, R.; Denis, D.; Lecart, M. P., and Franchimont, P. Salmon calcitonin: state of the art in prevention of postmenopausal bone loss? Acta Belg Med Phys. 1989 Apr–1989 Jun 30; 12(2):41–6. Rec #: 2705
551 Reginster JY, Deroisy R, Lecart MP, Sarlet N, Fontaine MA, Albert A, Franchimont P. (1990). Calcitonin and postmenopausal bone loss. Exp Gerontol.
552 Reginster JY, Taquet AN, Fraikin G, Gosset C, Zegels B. (1997). Parathyroid hormone in the treatment of involutional osteoporosis: back to the future. Osteoporos Int.
553 Reid DM, Adami S, Devogelaer JP, Chines AA. (2001). Risedronate increases bone density and reduces vertebral fracture risk within one year in men on corticosteroid therapy. Calcif Tissue Int.
554 Reid IR. (2002). Pharmacotherapy of osteoporosis in postmenopausal women: focus on safety. Expert Opin Drug Saf.
555 Reid IR, Heap SW, King AR, Ibbertson HK. (1988). Two-year follow-up of biphosphonate (APD) treatment in steroid osteoporosis. Lancet.
556 Reid IR, Schooler BA, Stewart AW. (1990). Prevention of glucocorticoid-induced osteoporosis. J Bone and Min Res.
557 Ribeiro A, DeVault KR, Wolfe JT, Stark ME. (1998). Alendronate-associated esophagitis: endoscopic and pathologic features. Gastrointest Endosc.
558 Riggs BL. (1991). Treatment of osteoporosis with sodium fluoride or parathyroid hormone. Am J Med.
559 Riggs BL, Melton LJ. (2002). Bone turnover matters: the raloxifene treatment paradox of dramatic decreases in vertebral fractures without commensurate increases in bone density. J Bone Miner Res.
560 Ringe, J. D. The interpretation of preclinical data in predicting bisphosphonate response in the treatment of osteoporosis. Clin Ther. 1998 Jul–1998 Aug 31; 20(4):648–60. Rec #: 2503
561 ---. Questions on the superiority of alfacalcidol over plain vitamin D in the treatment of glucocorticoidinduced osteoporosis. Rheumatol Int. 2004 Nov; 24(6):370. Rec #: 3401
562 Ringe JD, Dorst A, Faber H, Ibach K, Preuss J. (2003). Three-monthly ibandronate bolus injection offers favourable tolerability and sustained efficacy advantage over two years in established corticosteroid-induced osteoporosis. Rheumatology (Oxford).
563 Ringe JD, Dorst A, Faber H, Ibach K, Sorenson F. (2003). Intermittent intravenous ibandronate injections reduce vertebral fracture risk in corticosteroid-induced osteoporosis: results from a long-term comparative study. Osteoporos Int.
564 Ringe JD, Dorst A, Faber H, Ibach K, Sorenson F. (2003). Intermittent intravenous ibandronate injections reduce vertebral fracture risk in corticosteroid-induced osteoporosis: results from a long-term comparative study. Osteoporos Int.
565 Ringe JD, Faber H. (2000). Calcium and vitamin D in the prevention and treatment of glucocorticoid-induced osteoporosis. Clinical and Experimental Rheumatology.
566 Ringe JD, Orwoll E, Daifotis A, Lombardi A. (2002). Treatment of male osteoporosis: recent advances with alendronate. Osteoporos Int.
567 Ringe JD, Rovati LC. (2001). Treatment of osteoporosis in men with fluoride alone or in combination with bisphosphonates. Calcif Tissue Int.
568 Rizzato G, Tosi G, Schiraldi G, Montemurro L, Zanni D, Sisti S. (1988). Bone protection with salmon calcitonin (sCT) in the long-term steroid therapy of chronic sarcoidosis. Sarcoidosis.
569 Rizzoli, R. Long-term outcome of weekly bisphosphonates. Clin Orthop Relat Res. 2006; 44361–5. Rec #: 3273
570 Robinson E, Kimmick GG, Muss HB. (1996). Tamoxifen in postmenopausal women a safety perspective. Drugs Aging.
571 Roll KT. (2002). Risedronate: a new oral bisphosphonate. Clin Ther.
572 Roschger P, Rinnerthaler S, Yates J, Rodan GA, Fratzl P, Klaushofer K. (2001). Alendronate increases degree and uniformity of mineralization in cancellous bone and decreases the porosity in cortical bone of osteoporotic women. Bone.
573 Rosen CJ. (2005). Clinical practice. Postmenopausal osteoporosis. N Engl J Med.
574 ---. Restoring aging bones. Sci Am. 2003 Mar; 288(3):70–7. Rec #: 2250
575 ---. What's new with PTH in osteoporosis: where are we and where are we headed? Trends Endocrinol Metab. 2004 Jul; 15(5):229–33. Rec #: 2191
576 Rosen CJ, Bilezikian JP. (2001). Clinical review 123: Anabolic therapy for osteoporosis. J Clin Endocrinol Metab.
577 Rosen, C. J. and Rackoff, P. J. Emerging anabolic treatments for osteoporosis. Rheum Dis Clin North Am. 2001 Feb; 27(1):215–33, viii. Rec #: 2290
578 Rosenfeld JA. (2000). Can the prophylactic use of raloxifene, a selective estrogen-receptor modulator, prevent bone mineral loss and fractures in women with diagnosed osteoporosis or vertebral fractures?. West J Med.
579 Ross JR, Saunders Y, Edmonds PM, Patel S, Wonderling D, Normand C, Broadley K. (2004). A systematic review of the role of bisphosphonates in metastatic disease. Health Technol Assess.
580 Ross RW, Small EJ. (2002). Osteoporosis in men treated with androgen deprivation therapy for prostate cancer. J Urol.
581 Ross SD. (1997). Meta-analysis of prevention of nonvertebral fractures by alendronate. JAMA.
582 Rotella DP. (2002). Osteoporosis: challenges and new opportunities for therapy. Curr Opin Drug Discov Devel.
583 Roux C, Dougados M. (2002). Calcitonin in glucocorticoid-induced osteoporosis. Front Horm Res.
584 Roux C, Seeman E, Eastell R, Adachi J, Jackson RD, Felsenberg D, Songcharoen S, Rizzoli R, Di Munno O, Horlait S, Valent D, Watts NB. (2004). Efficacy of risedronate on clinical vertebral fractures within six months. Curr Med Res Opin.
585 Royce PC. (2001). The effect of risedronate on the risk of hip fracture in elderly women. N Engl J Med.
586 Rozenberg S, Kroll M, Pastijn A, Vandromme J. (1995). Osteoporosis prevention and treatment with sex hormone replacement therapy. Clin Rheumatol.
587 Rozkydal Z, Janicek P. (2003). The effect of alendronate in the treatment of postmenopausal osteoporosis. Bratisl Lek Listy.
588 Rubin MR, Bilezikian JP. (2002). New anabolic therapies in osteoporosis. Curr Opin Rheumatol.
589 ---. New anabolic therapies in osteoporosis. Endocrinol Metab Clin North Am. 2003 Mar; 32(1):285–307. Rec #: 2245
590 ---. The potential of parathyroid hormone as a therapy for osteoporosis. Int J Fertil Womens Med. 2002 May–2002 Jun 30; 47(3):103–15. Rec #: 2267
591 Rubin MR, Cosman F, Lindsay R, Bilezikian JP. (2002). The anabolic effects of parathyroid hormone. Osteoporos Int.
592 Ruggiero SL, Mehrotra B. (2004). Ten years of alendronate treatment for osteoporosis in postmenopausal women. N Engl J Med.
593 Ryan PJ, Fogelman I. (1994). Clinical experience with etidronate in osteoporosis. Clin Rheumatol.
594 Saag KG. (2004). Prevention of glucocorticoid-induced osteoporosis. South Med J.
595 Sahin FI, Sahin I, Ergun MA, Saracoglu OF. (2000). Effects of estrogen and alendronate on sister chromatid exchange (SCE) frequencies in postmenopausal osteoporosis patients. International Journal of Gynaecology and Obstetrics: the Official Organ of the International Federation of Gynaecology and Obstetrics.
596 Sahota O, Fowler I, Blackwell PJ, Lawson N, Cawte SA, San P, Masud T, Hosking DJ. (2000). A comparison of continuous alendronate, cyclical alendronate and cyclical etidronate with calcitriol in the treatment of postmenopausal vertebral osteoporosis: a randomized controlled trial. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
597 Sambrook, P. Vitamin D and fractures: quo vadis? Lancet. 2005 May 7–2005 May 13; 365(9471):1599–600. Rec #: 3390
598 Sambrook PN. (2005). How to prevent steroid induced osteoporosis. Ann Rheum Dis.
599 Sarli M, Fradinger E, Morillo S, Rey P, Zanchetta J. (1998). [Treatment of post menopausal osteoporosis with intravenous pamidronate in patients with esophagogastric pathology]. Medicina.
600 Sartori L, Adami S, Filipponi P, Crepaldi G. (2003). Injectable bisphosphonates in the treatment of postmenopausal osteoporosis. Aging Clin Exp Res.
601 Savvas M, Studd JW, Fogelman I, Dooley M, Montgomery J, Murby B. (1988). Skeletal effects of oral oestrogen compared with subcutaneous oestrogen and testosterone in postmenopausal women. BMJ.
602 Savvas M, Studd JW, Norman S, Leather AT, Garnett TJ, Fogelman I. (1992). Increase in bone mass after one year of percutaneous oestradiol and testosterone implants in post-menopausal women who have previously received long-term oral oestrogens. Br J Obstet Gynaecol.
603 Sawhney MS, Nelson DB. (2004). Alendronate-induced colon ulcers: case report of a new clinical entity. Gastrointest Endosc.
604 Sawka AM, Adachi JD, Ioannidis G, Olszynski WP, Brown JP, Hanley DA, Murray T, Josse R, Sebaldt RJ, Petrie A, Tenenhouse A, Papaioannou A, Goldsmith CH. (2003). What predicts early fracture or bone loss on bisphosphonate therapy?. J Clin Densitom.
605 Sawka AM, Thabane L, Papaioannou A, Gafni A, Hanley DA, Adachi JD. (2005). A systematic review of the effect of alendronate on bone mineral density in men. J Clin Densitom.
606 Scharla SH, Schacht E, Lempert UG. (2005). Alfacalcidol versus plain vitamin D in inflammation induced bone loss. J Rheumatol Suppl.
607 Schimmer RC, Bauss F. (2003). Effect of daily and intermittent use of ibandronate on bone mass and bone turnover in postmenopausal osteoporosis: a review of three phase II studies. Clin Ther.
608 Schnatz PF. (2006). Hormonal Therapy: Does It Increase or Decrease Cardiovascular Risk?. Obstet Gynecol Surv.
609 Schneyer CR. (1991). Calcitonin and the treatment of osteoporosis. Md Med J.
610 Schnitzer TJ. (2001). Update on alendronate for osteoporosis: once-weekly dosing. Expert Opin Pharmacother.
611 Schott AM, Dargent-Molina P, Meunier PJ. (2001). The effect of risedronate on the risk of hip fracture in elderly women. N Engl J Med.
612 Schousboe JT, Nyman JA, Kane RL, Ensrud KE. (2005). Cost-effectiveness of alendronate therapy for osteopenic postmenopausal women. Ann Intern Med.
613 Sebaldt, R. J.; Adachi, J. D.; Bensen, W. G.; Bianchi, F.; Cividano, A.; Craig, G. L.; Cranney, A. ; Kaminska, E.; Gordon, M.; Steele, M., and Goldsmith, C. Intermittent cyclic therapy with etidronate prevents corticosteroid-induced bone loss: two years of follow-up. 1996. Rec #: 1641
614 Sebaldt RJ, Ioannidis G, Adachi JD, Bensen WG, Bianchi F, Cividino A, Gordon M, Kaminska E, Scocchia T, Petrie A, Stephenson GF, Goldsmith CH. (1999). 36 month intermittent cyclical etidronate treatment in patients with established corticosteroid induced osteoporosis. The Journal of Rheumatology.
615 Seeman E, Delmas PD. (2001). Reconstructing the skeleton with intermittent parathyroid hormone. Trends Endocrinol Metab.
616 Seibel MJ, Naganathan V, Barton I, Grauer A. (2004). Relationship between pretreatment bone resorption and vertebral fracture incidence in postmenopausal osteoporotic women treated with risedronate. J Bone Miner Res.
617 Selby P. (1996). Alendronate treatment for osteoporosis: a review of the clinical evidence. Osteoporos Int.
618 Shaarawy M, Hasan M. (2001). Serum bone sialoprotein: a marker of bone resorption in postmenopausal osteoporosis. Scandinavian Journal of Clinical and Laboratory Investigation.
619 Shane E, Papadopoulos A, Staron RB, Addesso V, Donovan D, McGregor C, Schulman LL. (1999). Bone loss and fracture after lung transplantation. Transplantation.
620 Sharma RK, Kaushal R, Gupta A, Gupta S, Gultai S, Sharma AP. (2002). Role of oral alendronate in prevention of bone loss in adult nephrotics on steroid treatment. Indian Journal of Nephrology.
621 Shea, B.; Wells, G.; Cranney, A.; Zytaruk, N.; Robinson, V.; Griffith, L.; Hamel, C.; Ortiz, Z.; Peterson, J.; Adachi, J.; Tugwell, P., and Guyatt, G. Calcium supplementation on bone loss in postmenopausal women. Cochrane Database Syst Rev. 2004; (1):CD004526. Rec #: 3428
622 Shin MH, Holmes MD, Hankinson SE, Wu K, Colditz GA, Willett WC. (2002). Intake of dairy products, calcium, and vitamin D and risk of breast cancer. J Natl Cancer Inst.
623 Sickels JM, Nip CS. (2002). Risedronate for the prevention of fractures in postmenopausal osteoporosis. Ann Pharmacother.
624 Silberstein EB, Schnur W. (1992). Cyclic oral phosphate and etidronate increase femoral and lumbar bone mineral density and reduce lumbar spine fracture rate over three years. J Nucl Med.
625 Silverman SL, Watts NB, Delmas PD, Lange JL, Lindsay R. (2007). Effectiveness of bisphosphonates on nonvertebral and hip fractures in the first year of therapy: The risedronate and alendronate (REAL) cohort study. Osteoporos Int.
626 Siminoski K, Josse RG. (1996). Prevention and management of osteoporosis: consensus statements from the Scientific Advisory Board of the Osteoporosis Society of Canada. 9. Calcitonin in the treatment of osteoporosis. CMAJ.
627 Simon, J. A. and Mack, C. J. Prevention and management of osteoporosis. Clin Cornerstone. 2003; Suppl 2:S5–12. Rec #: 2205
628 ---. Treatment of osteoporosis: combination therapies. Int J Fertil Womens Med. 2003 May–2003 Jun 30; 48(3):127–31; discussion 137–8. Rec #: 2239
629 Simon, L. S. Osteoporosis. Clin Geriatr Med. 2005 Aug; 21(3):603–29, viii. Rec #: 2157
630 Sinigaglila L, Varenna M, Binelli L, Zucchi F, Ghiringhelli D, Fantini F. (2000). Bone mass in systemic lupus erythematosus. Clinical and Experimental Rheumatology.
631 Siris, E. Alendronate in the treatment of osteoporosis: a review of the clinical trials. J Womens Health Gend Based Med. 2000 Jul–2000 Aug 31; 9(6):599–606. Rec #: 2481
632 Slovik DM, Rosenthal DI, Doppelt SH, Potts JT, Daly MA, Campbell JA, Neer RM. (1986). Restoration of spinal bone in osteoporotic men by treatment with human parathyroid hormone (1–34) and 1,25-dihydroxyvitamin D. J Bone Miner Res.
633 Smith MR. (2003). Bisphosphonates to prevent osteoporosis in men receiving androgen deprivation therapy for prostate cancer. Drugs Aging.
634 Snyder PJ, Peachey H, Berlin JA, Hannoush P, Haddad G, Dlewati A, Santanna J, Loh L, Lenrow DA, Holmes JH, Kapoor SC, Atkinson LE, Strom BL. (2000). Effects of testosterone replacement in hypogonadal men. J Clin Endocrinol Metab.
635 Soileau KM. (2006). Oral post-surgical complications following the administration of bisphosphonates given for osteopenia related to malignancy. J Periodontol.
636 Solomon CG. (2002). Bisphosphonates and osteoporosis. N Engl J Med.
637 Solomon DH, Avorn J, Katz JN, Finkelstein JS, Arnold M, Polinski JM, Brookhart MA. (2005). Compliance with osteoporosis medications. Arch Intern Med.
638 Sone T, Fukunaga M, Ono S, Nishiyama T. (1995). A small dose of human parathyroid hormone(1–34) increased bone mass in the lumbar vertebrae in patients with senile osteoporosis. Miner Electrolyte Metab.
639 Sornay-Rendu E, Garnero P, Munoz F. (2003). Effect of withdrawal of hormone replacement therapy on bone mass and bone turnover: the OFELY study. Bone.
640 Sosa M, Hernandez D, Segarra MC, Gomez A, de la Pena E, Betancor P. (2002). Effect of two forms of alendronate administration upon bone mass after two years of treatment. Journal of Clinical Densitometry : the Official Journal of the International Society for Clinical Densitometry.
641 South-Paul JE. (2001). Osteoporosis: part II. Nonpharmacologic and pharmacologic treatment. Am Fam Physician.
642 Steelman J, Zeitler P. (2003). Treatment of symptomatic pediatric osteoporosis with cyclic single-day intravenous pamidronate infusions. J Pediatr.
643 Steinbuch M, D'Agostino RB, Mandel JS, Gabrielson E, McClung MR, Stemhagen A, Hofman A. (2002). Assessment of mortality in patients enrolled in a risedronate clinical trial program: a retrospective cohort study. Regul Toxicol Pharmacol.
644 Sternberg JL. (1995). Intermittent cyclic etidronate treatment of postmenopausal osteoporosis. Am J Med.
645 Struys A, Snelder AA, Mulder H. (1995). Cyclical etidronate reverses bone loss of the spine and proximal femur in patients with established corticosteroid-induced osteoporosis. Am J Med.
646 Sugiyama T, Tanaka H, Kawai S. (2004). Effects of parathyroid hormone and alendronate alone or in combination in osteoporosis. N Engl J Med.
647 Sutcliffe, A. Therapeutic interventions in osteoporosis. Nurs Times. 2002 Mar 7–2002 Mar 13; 98(10):52–4. Rec #: 2272
648 Taggart H, Bolognese MA, Lindsay R, Ettinger MP, Mulder H, Josse RG, Roberts A, Zippel H, Adami S, Ernst TF, Stevens KP. (2002). Upper gastrointestinal tract safety of risedronate: a pooled analysis of 9 clinical trials. Mayo Clin Proc.
649 Tashjian AH, Chabner BA. (2002). Commentary on clinical safety of recombinant human parathyroid hormone 1–34 in the treatment of osteoporosis in men and postmenopausal women. J Bone Miner Res.
650 Tauchmanova L, Ricci P, Serio B, Lombardi G, Colao A, Rotoli B, Selleri C. (2005). Short-term zoledronic acid treatment increases bone mineral density and marrow clonogenic fibroblast progenitors after allogeneic stem cell transplantation. The Journal of Clinical Endocrinology and Metabolism.
651 Terranova R, Luca S. (1999). Treatment of post-menopausal osteoporosis using etidronate. Minerva Medica.
652 Theodorou DJ, Theodorou SJ, Sartoris DJ. (2002). Treatment of osteoporosis: current status and recent advances. Compr Ther.
653 Thomas T, Barou O, Vico L, Alexandre C, Lafage-Proust MH. (1999). Recurrence of vertebral fracture with cyclical etidronate therapy in osteoporosis: histomorphometry and X-Ray microanalysis evaluation. J Bone Miner Res.
654 Tobias JH, Laversuch CJ, Chambers TJ, Gallagher AC. (1996). Aminohexane bisphosphonate suppresses bone turnover in postmenopausal women more rapidly than oestrogen-gestagen therapy. British Journal of Rheumatology.
655 Tolino A, Romano L, Ronsini S, Riccio S, Montemagno U. (1993). Treatment of postmenopausal osteoporosis with salmon calcitonin nasal spray: evaluation by bone mineral content and biochemical patterns. Int J Clin Pharmacol Ther Toxicol.
656 Toro J, Gentil MA, Garcia R, Perez-Valdivia MA, Garcia Avellano E, Algarra GR, Pereira P, Gonzalez-Roncero F, Mateos J. (2005). Alendronate in kidney transplant patients: a single-center experience. Transplant Proc.
657 Torregrosa JV, Moreno A, Gutierrez A, Vidal S, Oppenheimer F. (2003). Alendronate for treatment of renal transplant patients with osteoporosis. Transplantation Proceedings.
658 Tosteson AN, Grove MR, Hammond CS, Moncur MM, Ray GT, Hebert GM, Pressman AR, Ettinger B. (2003). Early discontinuation of treatment for osteoporosis. Am J Med.
659 Tovey FI, Hall ML, Ell PJ, Hobsley M. (1994). Cyclical etidronate therapy and postgastrectomy osteoporosis. Br J Surg.
660 Tracz MJ, Sideras K, Bolona ER, Haddad RM, Kennedy CC, Uraga MV, Caples SM, Erwin PJ, Montori VM. (2006). Testosterone use in men and its effects on bone health. A systematic review and meta-analysis of randomized placebo-controlled trials. J Clin Endocrinol Metab.
661 Tremaine WJ, Khosla S. (2002). Bisphosphonates and the upper gastrointestinal tract: skeletal gain without visceral pain?. Mayo Clin Proc.
662 Trombetti A, Gerbase MW, Spiliopoulos A, Slosman DO, Nicod LP, Rizzoli R. (2000). Bone mineral density in lung-transplant recipients before and after graft: prevention of lumbar spine post-transplantation-accelerated bone loss by pamidronate. The Journal of Heart and Lung Transplantation : the Official Publication of the International Society for Heart Transplantation.
663 Tsai KS, Ebeling PR, Riggs BL. (1989). Bone responsiveness to parathyroid hormone in normal and osteoporotic postmenopausal women. J Clin Endocrinol Metab.
664 Tsai, W. S.; Haghighi, K., and Placa, S. J. Bisphosphonate-induced osteonecrosis of the jaws: a case report and literature review. Gen Dent. 2006 May–2006 Jun 30; 54(3):215–9; quiz 220–2. Rec #: 3528
665 Tseng M, Breslow RA, Graubard BI, Ziegler RG. (2005). Dairy, calcium, and vitamin D intake and prostate cancer risk in the National Health and Nutrition Examination Epidemiologic Follow-up Study cohort. Am J Clin Nutr.
666 Tugwell, P. ; Wells, G.; Shea, B.; Peterson, J.; Cranney, A.; Henry, D.; O'Connell, D.; Robertson, J., and Gillespie, W. G. Hormone replacement therapy for osteoporosis in postmenopausal women. Cochrane Database of Systematic Reviews. 2005(3). Rec #: 1178
667 Turbi C, Herrero-Beaumont G, Acebes JC, Torrijos A, Grana J, Miguelez R, Sacristan J, Marin F. (2004). Compliance and satisfaction with raloxifene versus alendronate for the treatment of postmenopausal osteoporosis in clinical practice: An open-label, prospective, nonrandomized, observational study. Clin Ther.
668 Turkoski, B. Treating osteoporosis without hormones. Orthop Nurs. 2002 Sep–2002 Oct 31; 21(5):80–5. Rec #: 2258
669 Tursi A, Cuoco L, Cammarota G, Papa A, De Vitis I, Fedeli G, Gasbarrini G. (1997). Ulcerative oesophagitis due to alendronate. Ital J Gastroenterol Hepatol.
670 Ullom-Minnich P. (1999). Prevention of osteoporosis and fractures. Am Fam Physician.
671 Umland EM, Rinaldi C, Parks SM, Boyce EG. (1999). The impact of estrogen replacement therapy and raloxifene on osteoporosis, cardiovascular disease, and gynecologic cancers. Ann Pharmacother.
672 Utiger RD. (2001). Osteoporosis: the hormone connection. Health News.
673 Valk NK, Erdtsieck RJ, Algra D, Lamberts SW, Pols HA. (1995). Combined treatment of growth hormone and the bisphosphonate pamidronate, versus treatment with GH alone, in GH-deficient adults: the effects on renal phosphate handling, bone turnover and bone mineral mass. Clin Endocrinol (Oxf).
674 Valkema R, Vismans FJ, Papapoulos SE, Pauwels EK, Bijvoet OL. (1989). Maintained improvement in calcium balance and bone mineral content in patients with osteoporosis treated with the bisphosphonate APD. Bone Miner.
675 van Staa T, Abenhaim L, Cooper C. (1997). Upper gastrointestinal adverse events and cyclical etidronate. Am J Med.
676 van Staa, T. P. The Pathogenesis, Epidemiology and Management of Glucocorticoid-Induced Osteoporosis. Calcif Tissue Int. 2006 Sep 11. Rec #: 3435
677 van Staa TP, Abenhaim L, Cooper C. (1998). Use of cyclical etidronate and prevention of non-vertebral fractures. Br J Rheumatol.
678 Vanderschueren D, Vandenput L. (2000). Androgens and osteoporosis. Andrologia.
679 Vasikaran SD, Khan S, McCloskey EV, Kanis JA. (1995). Sustained response to intravenous alendronate in postmenopausal osteoporosis. Bone.
680 Vegni FE, Corradini C, Privitera G. (2004). Effects of parathyroid hormone and alendronate alone or in combination in osteoporosis. N Engl J Med.
681 Vieth R. (2005). The role of vitamin D in the prevention of osteoporosis. Ann Med.
682 Vieth R, Cole DE. (2005). Teriparatide, osteoporosis, calcium, and vitamin D. N Engl J Med.
683 Vilches AR, Perez V, Suchecki DE. (1998). Raloxifene-associated hepatitis. Lancet.
684 Villareal DT, Holloszy JO, Kohrt WM. (2000). Effects of DHEA replacement on bone mineral density and body composition in elderly women and men. Clinical Endocrinology.
685 Villareal DT, Rupich RC, Pacifici R, Griffin MG, Maggio D, Avioli LV, Civitelli R. (1992). Effect of estrogen and calcitonin on vertebral bone density and vertebral height in osteoporotic women. Osteoporos Int.
686 Von Heideken Wagert P, Littbrand H, Johansson A, Nordstrom P, Gustafson Y. (2002). Jumping exercises with and without raloxifene treatment in healthy elderly women. J Bone Miner Metab.
687 Vondracek SF, Hansen LB. (2004). Current approaches to the management of osteoporosis in men. Am J Health Syst Pharm.
688 Voskaridou E, Terpos E, Spina G, Palermos J, Rahemtulla A, Loutradi A, Loukopoulos D. (2003). Pamidronate is an effective treatment for osteoporosis in patients with beta-thalassaemia. Br J Haematol.
689 Wallach, S. The role of calcitonin treatment in postmenopausal osteoporosis. Orthop Rev. 1992 Sep; 21(9):1034–42, 1130–1. Rec #: 2684
690 Wallach S, Aloia J, Cohn S. (1972). Treatment of osteoporosis with calcitonin. Semin Drug Treat.
691 Wallach S, Cohn SH, Atkins HL, Ellis KJ, Kohberger R, Aloia JF, Zanzi I. (1977). Effect of salmon calcitonin on skeletal mass in osteoporosis. Current Therapeutic Research Clinical and Experimental.
692 Ward RL, Morgan G, Dalley D, Kelly PJ. (1993). Tamoxifen reduces bone turnover and prevents lumbar spine and proximal femoral bone loss in early postmenopausal women. Bone Miner.
693 Wasnich RD, Miller PD. (2000). Antifracture efficacy of antiresorptive agents are related to changes in bone density. J Clin Endocrinol Metab.
694 Watts NB. (2003). Bisphosphonate treatment of osteoporosis. Clin Geriatr Med.
695 ---. Efficacy of teriparatide and alendronate on nonvertebral fractures. J Clin Endocrinol Metab. 2003 Mar; 88(3):1402–3; author reply 1403. Rec #: 2247
696 ---. Risedronate for the prevention and treatment of postmenopausal osteoporosis: results from recent clinical trials. Osteoporos Int. 2001 Dec; 12 Suppl 3:S17–22. Rec #: 2457
697 ---. Treatment of osteoporosis with bisphosphonates. Rheum Dis Clin North Am. 1994 Aug; 20(3):717–34. Rec #: 2556
698 ---. Treatment of osteoporosis with bisphosphonates. Endocrinol Metab Clin North Am. 1998 Jun; 27(2):419–39. Rec #: 2508
699 Watts NB, Becker P. (1999). Alendronate increases spine and hip bone mineral density in women with postmenopausal osteoporosis who failed to respond to intermittent cyclical etidronate. Bone.
700 Watts NB, Cooper C, Lindsay R, Eastell R, Manhart MD, Barton IP, van Staa TP, Adachi JD. (2004). Relationship between changes in bone mineral density and vertebral fracture risk associated with risedronate: greater increases in bone mineral density do not relate to greater decreases in fracture risk. J Clin Densitom.
701 Watts NB, Lindsay R, Li Z, Kasibhatla C, Brown J. (2003). Use of matched historical controls to evaluate the anti-fracture efficacy of once-a-week risedronate. Osteoporos Int.
702 Watts, N. B.; Worley, K.; Solis, A.; Doyle, J., and Sheer, R. Comparison of risedronate to alendronate and calcitonin for early reduction of nonvertebral fracture risk: results from a managed care administrative claims database. J Manag Care Pharm. 2004 Mar–2004 Apr 30; 10(2):142–51. Rec #: 2401
703 Weber TJ, Drezner MK. (2001). Effect of alendronate on bone mineral density in male idiopathic osteoporosis. Metabolism.
704 Weiss M, Vered I, Foldes AJ, Cohen YC, Shamir-Elron Y, Ish-Shalom S. (2005). Treatment preference and tolerability with alendronate once weekly over a 3-month period: an Israeli multi-center study. Aging Clin Exp Res.
705 Weiss NS, Ure CL, Ballard JH, Williams AR, Daling JR. (1980). Decreased risk of fractures of the hip and lower forearm with postmenopausal use of estrogen. N Engl J Med.
706 Wells G, Tugwell P, Shea B. (2002). Meta-analysis of the efficacy of hormone replacement therapy in treating and preventing osteoporosis in postmenopausal women. Endocr Rev.
707 Whitfield JF. (2003). How to grow bone to treat osteoporosis and mend fractures. Curr Osteoporos Rep.
708 ---. Osteogenic PTHs and vascular ossification-Is there a danger for osteoporotics? J Cell Biochem. 2005 Jun 1; 95(3):437–44. Rec #: 2145
709 Whitfield JF, Morley P, Willick GE. (1999). The bone-building action of the parathyroid hormone: implications for the treatment of osteoporosis. Drugs Aging.
710 ---. Parathyroid hormone, its fragments and their analogs for the treatment of osteoporosis. Treat Endocrinol. 2002; 1(3):175–90. Rec #: 2160
711 Willhite, S. L.; Goebel, S. R., and Scoggin, J. A. Raloxifene provides an alternative for osteoporosis prevention. Ann Pharmacother. 1998 Jul–1998 Aug 31; 32(7–8):834–7. Rec #: 2619
712 Wimalawansa SJ. (2000). Prevention and treatment of osteoporosis: efficacy of combination of hormone replacement therapy with other antiresorptive agents. J Clin Densitom.
713 Winzenberg T, Shaw K, Fryer J, Jones G. (2006). Effects of calcium supplementation on bone density in healthy children: meta-analysis of randomised controlled trials. BMJ.
714 Wolfhagen FH, van Buuren HR, Vleggaar FP, Schalm SW. (2000). Management of osteoporosis in primary biliary cirrhosis. Baillieres Best Pract Res Clin Gastroenterol.
715 Woo T, Adachi JD. (2001). Role of bisphosphonates and calcitonin in the prevention and treatment of osteoporosis. Best Pract Res Clin Rheumatol.
716 Woolf AD, Akesson K. (2003). Preventing fractures in elderly people. BMJ.
717 Wu F, Ames R, Clearwater J, Evans MC, Gamble G, Reid IR. (2002). Prospective 10-year study of the determinants of bone density and bone loss in normal postmenopausal women, including the effect of hormone replacement therapy. Clin Endocrinol (Oxf).
718 Wu K, Willett WC, Fuchs CS, Colditz GA, Giovannucci EL. (2002). Calcium intake and risk of colon cancer in women and men. J Natl Cancer Inst.
719 Xu L, McElduff P, D'Este C, Attia J. (2004). Does dietary calcium have a protective effect on bone fractures in women? A meta-analysis of observational studies. Br J Nutr.
720 Yamamoto H, Kasayama S, Fujita M, Fujita K, Morimoto Y, Kawase I, Miyatake A. (2005). Improvement of reduced bone mineral density by intermittent cyclical etidronate in postmenopausal asthmatic patients receiving inhaled corticosteroids. Allergology International.
721 Yates J, Barrett-Connor E, Barlas S, Chen YT, Miller PD, Siris ES. (2004). Rapid loss of hip fracture protection after estrogen cessation: evidence from the National Osteoporosis Risk Assessment. Obstet Gynecol.
722 Younes H, Farhat G, el-Hajj Fuleihan G. (2002). Efficacy and tolerability of cyclical intravenous pamidronate in patients with low bone mass. J Clin Densitom.
723 Young JH. (1998). Tolerability of alendronate. Manufacturer's comment. BMJ.
724 Zacharin MR, Pua J, Kanumakala S. (2003). Bone mineral density outcomes following long-term treatment with subcutaneous testosterone pellet implants in male hypogonadism. Clin Endocrinol (Oxf).
725 Zamberlan N, Castello R, Gatti D, Rossini M, Braga V, Fracassi E, Adami S. (1997). Intermittent Etidronate partially prevents bone loss in hirsute hyperandrogenic women treated with GnRH agonist. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
726 Zanchetta JR, Plotkin H, Roldan EJ. (1996). Mineral density gain in vertebrae of osteoporotic women on oral pamidronate reverts a year after treatment discontinuance. Calcif Tissue Int.
727 Zidan J, Keidar Z, Basher W, Israel O. (2004). Effects of tamoxifen on bone mineral density and metabolism in postmenopausal women with early-stage breast cancer. Med Oncol.
728 Zizic TM. (2004). Pharmacologic prevention of osteoporotic fractures. Am Fam Physician.

## REJECTED: Did not include marker -FRACTURE

1 Abate G, Taormina F, Brillante C, Fraccalaglio L. (1994). [The effects of the carbocalcitonin + arginine-lysine-lactose combination in senile involutional osteoporosis]. Minerva Medica.
2 Adachi JD, Adami S, Kulkarni PM, Wong M, Stock JL. (2005). Similar proportions of women lose bone mineral density with raloxifene or alendronate treatment. J Clin Densitom.
3 Adachi JD, Adami S, Miller PD, Olszynski WP, Kendler DL, Silverman SL, Licata AA, Li Z, Gomez-Panzani E. (2001). Tolerability of risedronate in postmenopausal women intolerant of alendronate. Aging (Milano).
4 Adami S, Baroni MC, Broggini M, Carratelli L, Caruso I, Gnessi L, Laurenzi M, Lombardi A, Norbiato G, Ortolani S, et al. (1993). Treatment of postmenopausal osteoporosis with continuous daily oral alendronate in comparison with either placebo or intranasal salmon calcitonin. Osteoporos Int.
5 Adami S, Bruni V, Bianchini D, Becorpi A, Lombardi P, Campagnoli C, Ferrari A, Marchesoni T, Balena R. (2000). Prevention of early postmenopausal bone loss with cyclical etidronate. J Endocrinol Invest.
6 Adami S, Felsenberg D, Christiansen C, Robinson J, Lorenc RS, Mahoney P, Coutant K, Schimmer RC, Delmas PD. (2004). Efficacy and safety of ibandronate given by intravenous injection once every 3 months. Bone.
7 Adami S, Passeri M, Ortolani S, Broggini M, Carratelli L, Caruso I, Gandolini G, Gnessi L, Laurenzi M, Lombardi A, et al. (1995). Effects of oral alendronate and intranasal salmon calcitonin on bone mass and biochemical markers of bone turnover in postmenopausal women with osteoporosis. Bone.
8 Aloia JF, Talwar SA, Pollack S, Yeh J. (2005). A randomized controlled trial of vitamin D3 supplementation in African American women. Arch Intern Med.
9 Aloia JF, Vaswani A, Meunier PJ, Edouard CM, Arlot ME, Yeh JK, Cohn SH. (1987). Coherence treatment of postmenopausal osteoporosis with growth hormone and calcitonin. Calcified Tissue International.
10 Amory JK, Watts NB, Easley KA, Sutton PR, Anawalt BD, Matsumoto AM, Bremner WJ, Tenover JL. (2004). Exogenous testosterone or testosterone with finasteride increases bone mineral density in older men with low serum testosterone. The Journal of Clinical Endocrinology and Metabolism.
11 Anderson GL, Judd HL, Kaunitz AM, Barad DH, Beresford SA, Pettinger M, Liu J, McNeeley SG, Lopez AM. (2003). Effects of estrogen plus progestin on gynecologic cancers and associated diagnostic procedures: the Women's Health Initiative randomized trial. JAMA.
12 Arlot M, Meunier PJ, Boivin G, Haddock L, Tamayo J, Correa-Rotter R, Jasqui S, Donley DW, Dalsky GP, Martin JS, Eriksen EF. (2005). Differential effects of teriparatide and alendronate on bone remodeling in postmenopausal women assessed by histomorphometric parameters. J Bone Miner Res.
13 Arnala I, Saastamoinen J, Alhava EM. (1996). Salmon calcitonin in the prevention of bone loss at perimenopause. Bone.
14 Barrett-Connor E, Cauley JA, Kulkarni PM, Sashegyi A, Cox DA, Geiger MJ. (2004). Risk-benefit profile for raloxifene: 4-year data From the Multiple Outcomes of Raloxifene Evaluation (MORE) randomized trial. Journal of Bone and Mineral Research : the Official Journal of the American Society for Bone and Mineral Research.
15 Barrett-Connor E, Grady D, Sashegyi A, Anderson PW, Cox DA, Hoszowski K, Rautaharju P, Harper KD. (2002). Raloxifene and cardiovascular events in osteoporotic postmenopausal women: four-year results from the MORE (Multiple Outcomes of Raloxifene Evaluation) randomized trial. JAMA.
16 Barrett-Connor E, Ensrud KE, Harper K, Mason TM, Sashegyi A, Krueger KA, Anderson PW. (2003). Post hoc analysis of data from the Multiple Outcomes of Raloxifene Evaluation (MORE) trial on the effects of three years of raloxifene treatment on glycemic control and cardiovascular disease risk factors in women with and without type 2 diabetes. Clinical Therapeutics.
17 Bartram SA, Peaston RT, Rawlings DJ, Francis RM, Thompson NP. (2003). A randomized controlled trial of calcium with vitamin D, alone or in combination with intravenous pamidronate, for the treatment of low bone mineral density associated with Crohn's disease. Alimentary Pharmacology & Therapeutics.
18 Bekker PJ, Holloway DL, Rasmussen AS, Murphy R, Martin SW, Leese PT, Holmes GB, Dunstan CR, DePaoli AM. (2004). A single-dose placebo-controlled study of AMG 162, a fully human monoclonal antibody to RANKL, in postmenopausal women. Journal of Bone and Mineral Research : the Official Journal of the American Society for Bone and Mineral Research.
19 Bell NH, Bilezikian JP, Bone HG, Kaur A, Maragoto A, Santora AC. (2002). Alendronate increases bone mass and reduces bone markers in postmenopausal African-American women. The Journal of Clinical Endocrinology and Metabolism.
20 Bianda T, Linka A, Junga G, Brunner H, Steinert H, Kiowski W, Schmid C. (2000). Prevention of osteoporosis in heart transplant recipients: a comparison of calcitriol with calcitonin and pamidronate. Calcified Tissue International.
21 Bjarnason NH, Delmas PD, Mitlak BH, Shah AS, Huster WJ, Draper MW, et al. (1998). Raloxifene maintains favourable effects on bone mineral density, bone turnover and serum lipids without endometrial stimulation in postmenopausal women. 3-year study results [abstract]. Osteoporos Int.
22 Blake GM, Herd RJ, Fogelman I. (1996). A longitudinal study of supine lateral DXA of the lumbar spine: a comparison with posteroanterior spine, hip and total-body DXA. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
23 Blake GM, Herd RJ, Patel R, Fogelman I. (2000). The effect of weight change on total body dual-energy X-ray absorptiometry: results from a clinical trial. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
24 Blumel JE, Castelo-Branco C, de la Cuadra G, Maciver L, Moreno M, Haya J. (2003). Alendronate daily, weekly in conventional tablets and weekly in enteric tablets: preliminary study on the effects in bone turnover markers and incidence of side effects. Journal of Obstetrics and Gynaecology (Tokyo, Japan).
25 Bohning W, Ringe JD, Welzel D, Bode V. (1990). [Intranasal salmon calcitonin for the prophylaxis of bone mineral loss in steroid-treated chronic obstructive lung diseases]. Arzneimittel-Forschung.
26 Boivin G, Lips P, Ott SM, Harper KD, Sarkar S, Pinette KV, Meunier PJ. (2003). Contribution of raloxifene and calcium and vitamin D3 supplementation to the increase of the degree of mineralization of bone in postmenopausal women. J Clin Endocrinol Metab.
27 Boivin GY, Chavassieux PM, Santora AC, Yates J, Meunier PJ. (2000). Alendronate increases bone strength by increasing the mean degree of mineralization of bone tissue in osteoporotic women. Bone.
28 Borah B, Dufresne TE, Chmielewski PA, Johnson TD, Chines A, Manhart MD. (2004). Risedronate preserves bone architecture in postmenopausal women with osteoporosis as measured by three-dimensional microcomputed tomography. Bone.
29 Bouxsein ML, Parker RA, Greenspan SL. (1999). Forearm bone mineral densitometry cannot be used to monitor response to alendronate therapy in postmenopausal women. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
30 Braith RW, Magyari PM, Fulton MN, Aranda J, Walker T, Hill JA. (2003). Resistance exercise training and alendronate reverse glucocorticoid-induced osteoporosis in heart transplant recipients. The Journal of Heart and Lung Transplantation : the Official Publication of the International Society for Heart Transplantation.
31 Bravenboer N, Papapoulos SE, Holzmann P, Hamdy NA, Netelenbos JC, Lips P. (1999). Bone histomorphometric evaluation of pamidronate treatment in clinically manifest osteoporosis. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
32 Brazier M, Grados F, Kamel S, Mathieu M, Morel A, Maamer M, Sebert JL, Fardellone P. (2005). Clinical and laboratory safety of one year's use of a combination calcium + vitamin D tablet in ambulatory elderly women with vitamin D insufficiency: results of a multicenter, randomized, double-blind, placebo-controlled study. Clin Ther.
33 Buxton EC, Yao W, Lane NE. (2004). Changes in serum receptor activator of nuclear factor-kappaB ligand, osteoprotegerin, and interleukin-6 levels in patients with glucocorticoid-induced osteoporosis treated with human parathyroid hormone (1–34). The Journal of Clinical Endocrinology and Metabolism.
34 Cagnacci A, Arangino S, Renzi A, Zanni AL, Volpe A. (2003). Raloxifene does not influence flow-mediated endothelium-dependent and endothelium-independent vasodilatation of osteopenic postmenopausal women. American Journal of Obstetrics and Gynecology.
35 Cagnacci A, Zanni AL, Volpe A. (2003). Administration of raloxifene does not influence 24-hour ambulatory blood pressure of postmenopausal women with osteopenia: a double-blind placebo-controlled study. American Journal of Obstetrics and Gynecology.
36 Cameron LD, Leventhal H, Love RR, Patrick-Miller LJ. (2002). Trait anxiety and tamoxifen effects on bone mineral density and sex hormone- binding globulin. Psychosomatic Medicine.
37 Campusano C, Lopez JM, Campino C, Cardenas I, Rojas A. (2000). [Effect of low calcitonin doses on bone remodeling in postmenopausal women with high bone turnover rate]. Revista Medica De Chile.
38 Cantatore FP, Loperfido MC, Mancini L, Carrozzo M. (1992). Effect of calcitonin or the anabolic steroid Decadurabolin on serum beta 2 microglobulin in osteoporotic postmenopausal women. J Rheumatol.
39 Casez JP, Tschopp P, Sandberg Tschopp A, Lippuner K, Zingg E, Jaeger P. (2003). Effects of nasal calcitonin on bone mineral density following parathyroidectomy in patients with primary hyperparathyroidism. Hormone Research.
40 Cauley JA, Norton L, Lippman ME, Eckert S, Krueger KA, Purdie DW, Farrerons J, Karasik A, Mellstrom D, Ng KW, Stepan JJ, Powles TJ, Morrow M, Costa A, Silfen SL, Walls EL, Schmitt H, Muchmore DB, Jordan VC, Ste-Marie LG. (2001). Continued breast cancer risk reduction in postmenopausal women treated with raloxifene: 4-year results from the MORE trial. Multiple outcomes of raloxifene evaluation. Breast Cancer Research and Treatment.
41 Cecchettin M, Bellometti S, Cremonesi G, Solimeno LP, Torri G. (1995). Metabolic and bone effects after administration of ipriflavone and salmon calcitonin in postmenopausal osteoporosis. Biomedicine & Pharmacotherapy = Biomedecine & Pharmacotherapie.
42 Chailurkit LO, Jongjaroenprasert W, Rungbunnapun S, Ongphiphadhanakul B, Sae-tung S, Rajatanavin R. (2003). Effect of alendronate on bone mineral density and bone turnover in Thai postmenopausal osteoporosis. Journal of Bone and Mineral Metabolism.
43 Chapurlat RD, Blackwell T, Bauer DC, Cummings SR. (2001). Changes in biochemical markers of bone turnover in women treated with raloxifene: influence of regression to the mean. Osteoporos Int.
44 Chavassieux PM, Arlot ME, Reda C, Wei L, Yates AJ, Meunier PJ. (1997). Histomorphometric assessment of the long-term effects of alendronate on bone quality and remodeling in patients with osteoporosis. J Clin Invest.
45 Chavassieux PM, Arlot ME, ; Roux JP, Portero N, Daifotis A, Yates AJ, Hamdy NA, Malice MP, Freedholm D, Meunier PJ. (2000). Effects of alendronate on bone quality and remodeling in glucocorticoid-induced osteoporosis: a histomorphometric analysis of transiliac biopsies. J Bone Miner Res.
46 Chen M, Chow SN. (2001). Additive effect of alfacalcidol on bone mineral density of the lumbar spine in Taiwanese postmenopausal women treated with hormone replacement therapy and calcium supplementation: a randomized 2-year study. Clinical Endocrinology.
47 Cheng ZQ, Yin W, Fan JY, Ma TJ. (2002). [The efficacy of alendronate in the prevention and treatment of postmenopausal osteoporosis]. Zhongguo Yi Xue Ke Xue Yuan Xue Bao Acta Academiae Medicinae Sinicae.
48 Chesnut CH, Bell NH, Clark GS, Drinkwater BL, English SC, Johnson CC, Notelovitz M, Rosen C, Cain DF, Flessland KA, Mallinak NJ. (1997). Hormone replacement therapy in postmenopausal women: urinary N-telopeptide of type I collagen monitors therapeutic effect and predicts response of bone mineral density. Am J Med.
49 Chilibeck PD, Davison KS, Whiting SJ, Suzuki Y, Janzen CL, Peloso P. (2002). The effect of strength training combined with bisphosphonate (etidronate) therapy on bone mineral, lean tissue, and fat mass in postmenopausal women. Can J Physiol Pharmacol.
50 Chlebowski RT, Hendrix SL, Langer RD, Stefanick ML, Gass M, Lane D, Rodabough RJ, Gilligan MA, Cyr MG, Thomson CA, Khandekar J, Petrovitch H, McTiernan A. (2003). Influence of estrogen plus progestin on breast cancer and mammography in healthy postmenopausal women: the Women's Health Initiative Randomized Trial. JAMA.
51 Chlebowski RT, Wactawski-Wende J, Ritenbaugh C, Hubbell FA, Ascensao J, Rodabough RJ, Rosenberg CA, Taylor VM, Harris R, Chen C, Adams-Campbell LL, White E. (2004). Estrogen plus progestin and colorectal cancer in postmenopausal women. N Engl J Med.
52 Chow CC, Chan WB, Li JK, Chan NN, Chan MH, Ko GT, Lo KW, Cockram CS. (2003). Oral alendronate increases bone mineral density in postmenopausal women with primary hyperparathyroidism. J Clin Endocrinol Metab.
53 Ciuffetti G, Ciacca A, Lombardini R, Scarponi AM, Paltriccia R, Orecchini G. (1991). [Rheologic effects of salmon calcitonin on post-menopausal osteoporosis. Results of a preliminary study]. Minerva Medica.
54 Civitelli R, Agnusdei D, Nardi P, Zacchei F, Avioli LV, Gennari C. (1988). Effects of one-year treatment with estrogens on bone mass, intestinal calcium absorption, and 25-hydroxyvitamin D-1 alpha-hydroxylase reserve in postmenopausal osteoporosis. Calcif Tissue Int.
55 Combe B, Cohen C, Aubin F. (1997). Equivalence of nasal spray and subcutaneous formulations of salmon calcitonin. Calcified Tissue International.
56 Cooper C, Emkey RD, McDonald RH, Hawker G, Bianchi G, Wilson K, Schimmer RC. (2003). Efficacy and safety of oral weekly ibandronate in the treatment of postmenopausal osteoporosis. J Clin Endocrinol Metab.
57 Cosman F, Nieves J, Woelfert L, Gordon S, Shen V, Lindsay R. (1998). Parathyroid responsivity in postmenopausal women with osteoporosis during treatment with parathyroid hormone. J Clin Endocrinol Metab.
58 Cosman F, Nieves JW, Luckey M. (2003). Daily versus cyclic PTH combined with alendronate versus alendronate alone for treatment of osteoporosis. J Bone Miner Res.
59 Crawford BA, Kam C, Pavlovic J, Byth K, Handelsman DJ, Angus PW, McCaughan GW. (2006). Zoledronic acid prevents bone loss after liver transplantation: a randomized, double-blind, placebo-controlled trial. Ann Intern Med.
60 Crawford BA, Liu PY, Kean MT, Bleasel JF, Handelsman DJ. (2003). Randomized placebo-controlled trial of androgen effects on muscle and bone in men requiring long-term systemic glucocorticoid treatment. The Journal of Clinical Endocrinology and Metabolism.
61 Cryer B, Binkley N, Simonelli C, Lewiecki EM, Lanza F, Chen E, Petruschke RA, Mullen C, de Papp AE. (2005). A randomized, placebo-controlled, 6-month study of once-weekly alendronate oral solution for postmenopausal osteoporosis. Am J Geriatr Pharmacother.
62 Cryer B, Miller P, Petruschke RA, Chen E, Geba GP, Papp AE. (2005). Upper gastrointestinal tolerability of once weekly alendronate 70 mg with concomitant non-steroidal anti-inflammatory drug use. Aliment Pharmacol Ther.
63 Cummings SR, Eckert S, Krueger KA, Grady D, Powles TJ, Cauley JA, Norton L, Nickelsen T, Bjarnason NH, Morrow M, Lippman ME, Black D, Glusman JE, Costa A, Jordan VC. (1999). The effect of raloxifene on risk of breast cancer in postmenopausal women: results from the MORE randomized trial. Multiple Outcomes of Raloxifene Evaluation. JAMA.
64 Curb JD, Prentice RL, Bray PF, Langer RD, Van Horn L, Barnabei VM, Bloch MJ, Cyr MG, Gass M, Lepine L, Rodabough RJ, Sidney S, Uwaifo GI, Rosendaal FR. (2006). Venous thrombosis and conjugated equine estrogen in women without a uterus. Arch Intern Med.
65 Cushman M, Kuller LH, Prentice R, Rodabough RJ, Psaty BM, Stafford RS, Sidney S, Rosendaal FR. (2004). Estrogen plus progestin and risk of venous thrombosis. JAMA.
66 D'Amelio P, Muratore M, Tinelli F, Tamone C, Cosentino L, Quarta E, Calcagnile F, Carlo Isaia G. (2003). Effect of raloxifene and clodronate on bone density in postmenopausal osteoporotic women. International Journal of Tissue Reactions.
67 Dal Negro R, Turco P, Pomari C, Trevisan F. (1991). Calcitonin nasal spray in patients with chronic asthma: a double-blind crossover study vs placebo. Int J Clin Pharmacol Ther Toxicol.
68 Daly RM, Brown M, Bass S, Kukuljan S, Nowson C. (2006). Calcium- and vitamin D3-fortified milk reduces bone loss at clinically relevant skeletal sites in older men: a 2-year randomized controlled trial. J Bone Miner Res.
69 Davas I, Altintas A, Yoldemir T, Varolan A, Yazgan A, Baksu B. (2003). Effect of daily hormone therapy and alendronate use on bone mineral density in postmenopausal women. Fertil Steril.
70 Davis SR, McCloud P, Strauss BJ, Burger H. (1995). Testosterone enhances estradiol's effects on postmenopausal bone density and sexuality. Maturitas.
71 Deal C, Omizo M, Schwartz EN, Eriksen EF, Cantor P, Wang J, Glass EV, Myers SL, Krege JH. (2005). Combination teriparatide and raloxifene therapy for postmenopausal osteoporosis: results from a 6-month double-blind placebo-controlled trial. J Bone Miner Res.
72 Decensi A, Robertson C, Viale G, Pigatto F, Johansson H, Kisanga ER, Veronesi P, Torrisi R, Cazzaniga M, Mora S, Sandri MT, Pelosi G, Luini A, Goldhirsch A, Lien EA, Veronesi U. (2003). A randomized trial of low-dose tamoxifen on breast cancer proliferation and blood estrogenic biomarkers. Journal of the National Cancer Institute.
73 Delmas PD, Balena R, Confravreux E, Hardouin C, Hardy P, Bremond A. (1997). Bisphosphonate risedronate prevents bone loss in women with artificial menopause due to chemotherapy of breast cancer: a double-blind, placebo-controlled study. J Clin Oncol.
74 Delmas PD, Bjarnason NH, Mitlak BH, Ravoux AC, Shah AS, Huster WJ, Draper M, Christiansen C. (1997). Effects of raloxifene on bone mineral density, serum cholesterol concentrations, and uterine endometrium in postmenopausal women. N Engl J Med.
75 Delmas PD, Ensrud KE, Harper K, Wu W, Adachi J, Estell R, et al. (2000). Effects of raloxifine on bone mineral density and biochemical markers of bone turnover in postmenopausal women in osteoporosis: 4-year results from the MORE trial [abstract]. J Bone Min Res.
76 Di Daniele N, Carbonelli MG, Candeloro N, Iacopino L, De Lorenzo A, Andreoli A. (2004). Effect of supplementation of calcium and vitamin D on bone mineral density and bone mineral content in peri- and post-menopause women; a double-blind, randomized, controlled trial. Pharmacol Res.
77 Di Somma C, Colao A, Pivonello R, Klain M, Faggiano A, Tripodi FS, Merola B, Salvatore M, Lombardi G. (1998). Effectiveness of chronic treatment with alendronate in the osteoporosis of Cushing's disease. Clinical Endocrinology.
78 Diamond TH, Winters J, Smith A, De Souza P, Kersley JH, Lynch WJ, Bryant C. (2001). The antiosteoporotic efficacy of intravenous pamidronate in men with prostate carcinoma receiving combined androgen blockade: a double blind, randomized, placebo-controlled crossover study. Cancer.
79 Dobnig H, Sipos A, Jiang Y, Fahrleitner-Pammer A, Ste-Marie LG, Gallagher JC, Pavo I, Wang J, Eriksen EF. (2005). Early changes in biochemical markers of bone formation correlate with improvements in bone structure during teriparatide therapy. J Clin Endocrinol Metab.
80 Doran PM, Riggs BL, Atkinson EJ, Khosla S. (2001). Effects of raloxifene, a selective estrogen receptor modulator, on bone turnover markers and serum sex steroid and lipid levels in elderly men. J Bone Miner Res.
81 Downs RW, Bell NH, Ettinger MP, Walsh BW, Favus MJ, Mako B, Wang L, Smith ME, Gormley GJ, Melton ME. (2000). Comparison of alendronate and intranasal calcitonin for treatment of osteoporosis in postmenopausal women. J Clin Endocrinol Metab.
82 Draper MW, Flowers DE, Huster WJ, Neild JA, Harper KD, Arnaud C. (1996). A controlled trial of raloxifene (LY139481) HCl: impact on bone turnover and serum lipid profile in healthy postmenopausal women. J Bone Miner Res.
83 Dufresne TE, Chmielewski PA, Manhart MD, Johnson TD, Borah B. (2003). Risedronate preserves bone architecture in early postmenopausal women in 1 year as measured by three-dimensional microcomputed tomography. Calcif Tissue Int.
84 Eastell R, Barton I, Hannon RA, Chines A, Garnero P, Delmas PD. (2003). Relationship of early changes in bone resorption to the reduction in fracture risk with risedronate. J Bone Miner Res.
85 Eiken P, Kolthoff N, Nielsen SP. (1996). Effect of 10 years' hormone replacement therapy on bone mineral content in postmenopausal women. Bone.
86 Eisman JA, Rizzoli R, Roman-Ivorra J, Lipschitz S, Verbruggen N, Gaines KA, Melton ME. (2004). Upper gastrointestinal and overall tolerability of alendronate once weekly in patients with osteoporosis: results of a randomized, double-blind, placebo-controlled study. Curr Med Res Opin.
87 El-Agroudy AE, El-Husseini AA, El-Sayed M, Mohsen T, Ghoneim MA. (2005). A prospective randomized study for prevention of postrenal transplantation bone loss. Kidney Int.
88 El-Agroudy A, El-Hussaini A, El-Sayed M, Ghoneim MA. (2003). Prevention of osteoporosis after kidney transplanatation: a prospective randomized study. Nephrology Dialysis Transplantation.
89 El-Husseini AA, El-Agroudy AE, El-Sayed MF, Sobh MA, Ghoneim MA. (2004). Treatment of osteopenia and osteoporosis in renal transplant children and adolescents. Pediatr Transplant.
90 Ellerington MC, Hillard TC, Whitcroft SI, Marsh MS, Lees B, Banks LM, Whitehead MI, Stevenson JC. (1996). Intranasal salmon calcitonin for the prevention and treatment of postmenopausal osteoporosis. Calcif Tissue Int.
91 Emkey R, Delmas PD, Goemaere S, Liberman UA, Poubelle PE, Daifotis AG, Verbruggen N, Lombardi A, Czachur M. (2003). Changes in bone mineral density following discontinuation or continuation of alendronate therapy in glucocorticoid-treated patients: a retrospective, observational study. Arthritis Rheum.
92 Ensrud K, Genazzani AR, Geiger MJ, McNabb M, Dowsett SA, Cox DA, Barrett-Connor E. (2006). Effect of raloxifene on cardiovascular adverse events in postmenopausal women with osteoporosis. Am J Cardiol.
93 Ensrud KE, Barrett-Connor EL, Schwartz A, Santora AC, Bauer DC, Suryawanshi S, Feldstein A, Haskell WL, Hochberg MC, Torner JC, Lombardi A, Black DM. (2004). Randomized trial of effect of alendronate continuation versus discontinuation in women with low BMD: results from the Fracture Intervention Trial long-term extension. J Bone Miner Res.
94 Eriksen EF, Melsen F, Sod E, Barton I, Chines A. (2002). Effects of long-term risedronate on bone quality and bone turnover in women with postmenopausal osteoporosis. Bone.
95 Evans RA, Somers NM, Dunstan CR, Royle H, Kos S. (1993). The effect of low-dose cyclical etidronate and calcium on bone mass in early postmenopausal women. Osteoporos Int.
96 Evio S, Tiitinen A, Laitinen K, Ylikorkala O, Valimaki MJ. (2004). Effects of alendronate and hormone replacement therapy, alone and in combination, on bone mass and markers of bone turnover in elderly women with osteoporosis. J Clin Endocrinol Metab.
97 Fairfield WP, Finkelstein JS, Klibanski A, Grinspoon SK. (2001). Osteopenia in eugonadal men with acquired immune deficiency syndrome wasting syndrome. The Journal of Clinical Endocrinology and Metabolism.
98 Fan SL, Kumar S, Cunningham J. (2003). Long-term effects on bone mineral density of pamidronate given at the time of renal transplantation. Kidney International.
99 Fan SL-S, Almond MK, Ball E, Evans K, Cunningham J. (2000). Pamidronate therapy as prevention of bone loss following renal transplantation. Kidney International.
100 Felsenberg D, Alenfeld F, Bock O, Hammermeister C, Gowan W. (1998). Placebo-controlled multicenter study of oral alendronate in postmenopausal osteoporotic women. FOSIT-Study-Group. Fosamax International Trial. Maturitas.
101 Finkelstein JS, Arnold AL. (1999). Increases in bone mineral density after discontinuation of daily human parathyroid hormone and gonadotropin-releasing hormone analog administration in women with endometriosis. The Journal of Clinical Endocrinology and Metabolism.
102 Finkelstein JS, Hayes A, Hunzelman JL, Wyland JJ, Lee H, Neer RM. (2003). The effects of parathyroid hormone, alendronate, or both in men with osteoporosis. N Engl J Med.
103 Finkelstein, J. S.; Klibanski, A.; Arnold, A. L.; Toth, T. L.; Hornstein, M. D., and Neer, R. M. Prevention of estrogen deficiency-related bone loss with human parathyroid hormone-(1–34): a randomized controlled trial. JAMA. 1998 Sep 23–1998 Sep 30; 280(12):1067–73. Rec #: 1065
104 Finkelstein JS, Klibanski A, Schaefer EH, Hornstein MD, Schiff I, Neer RM. (1994). Parathyroid hormone for the prevention of bone loss induced by estrogen deficiency. The New England Journal of Medicine.
105 Finkelstein JS, Leder BZ, Burnett SA, Wyland JJ, Lee H, de la Paz AV, Gibson K, Neer RM. (2006). Effects of teriparatide, alendronate, or both on bone turnover in osteoporotic men. J Clin Endocrinol Metab.
106 Flicker L, Hopper JL, Larkins RG, Lichtenstein M, Buirski G, Wark JD. (1997). Nandrolone decanoate and intranasal calcitonin as therapy in established osteoporosis. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
107 Fogelman I, Herd RJ, Blake GM, Balena R. (2000). Cyclical etidronate therapy for prevention of postmenopausal bone loss: a 1-year open-label follow-up study. Calcif Tissue Int.
108 Frediani B, Allegri A, Bisogno S, Marcolongo R. (1998). Effects of combined treatment with calcitriol plus alendronate on bone mass and bone turnover in postmenopausal osteoporosis: Two years of continuous treatment. Clinical Drug Investigation.
109 Freedman M, San Martin J, O'Gorman J, Eckert S, Lippman ME, Lo SC, Walls EL, Zeng J. (2001). Digitized mammography: a clinical trial of postmenopausal women randomly assigned to receive raloxifene, estrogen, or placebo. J Natl Cancer Inst.
110 Fuleihan Gel-H, Salamoun M, Mourad YA, Chehal A, Salem Z, Mahfoud Z, Shamseddine A. (2005). Pamidronate in the prevention of chemotherapy-induced bone loss in premenopausal women with breast cancer: a randomized controlled trial. J Clin Endocrinol Metab.
111 Garnero P, Shih WJ, Gineyts E, Karpf DB, Delmas PD. (1994). Comparison of new biochemical markers of bone turnover in late postmenopausal osteoporotic women in response to alendronate treatment. J Clin Endocrinol Metab.
112 Genant HK, Lang T, Fuerst T, Pinette KV, Zhou C, Thiebaud D, Diez-Perez A. (2004). Treatment with raloxifene for 2 years increases vertebral bone mineral density as measured by volumetric quantitative computed tomography. Bone.
113 Gennari, C. ; Agnusdei, D., and Camporeale, A. Effect of salmon calcitonin nasal spray on bone mass in patients with high turnover osteoporosis. 1993. Rec #: 1821
114 Gennari C, Agnusdei D, Montagnani M, Gonnelli S, Civitelli R. (1992). An effective regimen of intranasal salmon calcitonin in early postmenopausal bone loss. Calcif Tissue Int.
115 Gennari C, Gonnelli S, Monaci G, Campagna MS, Franci B. (1993). Pharmacodynamic activity of synthetic salmon calcitonin in osteoporotic patients: Comparison between rectal and intramuscular administration. Pilot study. Curr Ther Res Clin Exp.
116 Gertz BJ, Clemens JD, Holland SD, Yuan W, Greenspan S. (1998). Application of a new serum assay for type I collagen cross-linked N-telopeptides: assessment of diurnal changes in bone turnover with and without alendronate treatment. Calcified Tissue International.
117 Giannini S, D'Angelo A, Carraro G, Nobile M, Rigotti P, Bonfante L, Marchini F, Zaninotto M, Dalle Carbonare L, Sartori L, Crepaldi G. (2001). Alendronate prevents further bone loss in renal transplant recipients. Journal of Bone and Mineral Research : the Official Journal of the American Society for Bone and Mineral Research.
118 Gnudi S, Mongiorgi R, Moroni A, Bertocchi G. (1988). Densitometric analysis in in vivo evaluation of synthetic salmon calcitonin activity. J Clin Pharm Ther.
119 Going S, Lohman T, Houtkooper L, Metcalfe L, Flint-Wagner H, Blew R, Stanford V, Cussler E, Martin J, Teixeira P, Harris M, Milliken L, Figueroa-Galvez A, Weber J. (2003). Effects of exercise on bone mineral density in calcium-replete postmenopausal women with and without hormone replacement therapy. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
120 Golden NH, Iglesias EA, Jacobson MS, Carey D, Meyer W, Schebendach J, Hertz S, Shenker IR. (2005). Alendronate for the treatment of osteopenia in anorexia nervosa: a randomized, double-blind, placebo-controlled trial. J Clin Endocrinol Metab.
121 Gonnelli S, Agnusdei D, Camporeale A, Palmieri R, Gennari C. (1993). Effect of rectal salmon calcitonin treatment on bone mass and bone turnover in patients with established postmenopausal osteoporosis: A 1-year crossover study. Curr Ther Res Clin Exp.
122 Gonnelli S, Cepollaro C, Montagnani A, Bruni D, Caffarelli C, Breschi M, Gennari L, Gennari C, Nuti R. (2003). Alendronate treatment in men with primary osteoporosis: a three-year longitudinal study. Calcif Tissue Int.
123 Gonnelli S, Cepollaro C, Montomoli M, Gennari L, Montagnani A, Palmieri R, Gennari C. (1997). Treatment of post-menopausal osteoporosis with recombinant human growth hormone and salmon calcitonin: a placebo controlled study. Clin Endocrinol (Oxf).
124 Gonnelli S, Cepollaro C, Pondrelli C, Martini S, Montagnani A, Monaco R, Gennari C. (1999). Bone turnover and the response to alendronate treatment in postmenopausal osteoporosis. Calcif Tissue Int.
125 Gonnelli S, Cepollaro C, Pondrelli C, Martini S, Rossi S, Gennari C. (1996). Ultrasound parameters in osteoporotic patients treated with salmon calcitonin: a longitudinal study. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
126 Gonnelli S, Rottoli P, Cepollaro C, Pondrelli C, Cappiello V, Vagliasindi M, Gennari C. (1997). Prevention of corticosteroid-induced osteoporosis with alendronate in sarcoid patients. Calcified Tissue International.
127 Gozansky WS, Van Pelt RE, Jankowski CM, Schwartz RS, Kohrt WM. (2005). Protection of bone mass by estrogens and raloxifene during exercise-induced weight Loss. The Journal of Clinical Endocrinology and Metabolism.
128 Grady D, Ettinger B, Moscarelli E, Plouffe L, Sarkar S, Ciaccia A, Cummings S. (2004). Safety and adverse effects associated with raloxifene: multiple outcomes of raloxifene evaluation. Obstet Gynecol.
129 Greenspan S, Field-Munves E, Tonino R, Smith M, Petruschke R, Wang L, Yates J, de Papp AE, Palmisano J. (2002). Tolerability of once-weekly alendronate in patients with osteoporosis: a randomized, double-blind, placebo-controlled study. Mayo Clin Proc.
130 Greenspan SL, Emkey RD, Bone HG, Weiss SR, Bell NH, Downs RW, McKeever C, Miller SS, Davidson M, Bolognese MA, Mulloy AL, Heyden N, Wu M, Kaur A, Lombardi A. (2002). Significant differential effects of alendronate, estrogen, or combination therapy on the rate of bone loss after discontinuation of treatment of postmenopausal osteoporosis. A randomized, double-blind, placebo-controlled trial. Ann Intern Med.
131 Greenspan SL, Holland S, Maitland-Ramsey L, Poku M, Freeman A, Yuan W, Kher U, Gertz B. (1996). Alendronate stimulation of nocturnal parathyroid hormone secretion: a mechanism to explain the continued improvement in bone mineral density accompanying alendronate therapy. Proceedings of the Association of American Physicians.
132 Greenspan SL, Parker RA, Ferguson L, Rosen HN, Maitland-Ramsey L, Karpf DB. (1998). Early changes in biochemical markers of bone turnover predict the long-term response to alendronate therapy in representative elderly women: a randomized clinical trial. J Bone Miner Res.
133 Greenspan SL, Resnick NM, Parker RA. (2005). Early changes in biochemical markers of bone turnover are associated with long-term changes in bone mineral density in elderly women on alendronate, hormone replacement therapy, or combination therapy: a three-year, double-blind, placebo-controlled, randomized clinical trial. J Clin Endocrinol Metab.
134 Greenspan SL, Rosen HN, Parker RA. (2000). Early changes in serum N-telopeptide and C-telopeptide cross-linked collagen type 1 predict long-term response to alendronate therapy in elderly women. The Journal of Clinical Endocrinology and Metabolism.
135 Greenwald, M. W.; Gluck, O. S.; Lang, E., and Rakov, V. Oral hormone therapy with 17beta-estradiol and 17beta-estradiol in combination with norethindrone acetate in the prevention of bone loss in early postmenopausal women: dose-dependent effects. Menopause. 2005 Nov–2005 Dec 31; 12(6):741–8. Rec #: 3415
136 Grey AB, Stapleton JP, Evans MC, Tatnell MA, Ames RW, Reid IR. (1995). The effect of the antiestrogen tamoxifen on bone mineral density in normal late postmenopausal women. Am J Med.
137 Grigoriou O, Papoulias I, Vitoratos N, Papadias C, Konidaris S, Antoniou G, Chryssikopoulos A. (1997). Effects of nasal administration of calcitonin in oophorectomized women: 2-year controlled double-blind study. Maturitas.
138 Grotz WH, Rump LC, Niessen A, Schmidt-Gayk H, Reichelt A, Kirste G, Olschewski M, Schollmeyer PJ. (1998). Treatment of osteopenia and osteoporosis after kidney transplantation. Transplantation.
139 Gur A, Colpan L, Cevik R, Nas K, Jale Sarac A. (2005). Comparison of zinc excretion and biochemical markers of bone remodelling in the assessment of the effects of alendronate and calcitonin on bone in postmenopausal osteoporosis. Clin Biochem.
140 Gur A, Denli A, Cevikm R, Nas K, Karakoc M, Sarac AJ. (2003). The effects of alendronate and calcitonin on cytokines in postmenopausal osteoporosis: a 6-month randomized and controlled study. Yonsei Medical Journal.
141 Gurlek A, Bayraktar M, Gedik O. (1997). Comparison of calcitriol treatment with etidronate-calcitriol and calcitonin-calcitriol combinations in Turkish women with postmenopausal osteoporosis: a prospective study. Calcif Tissue Int.
142 Haas M, Leko-Mohr Z, Roschger P, Kletzmayr J, Schwarz C, Mitterbauer C, Steininger R, Grampp S, Klaushofer K, Delling G, Oberbauer R. (2003). Zoledronic acid to prevent bone loss in the first 6 months after renal transplantation. Kidney International.
143 Harris ST, Gertz BJ, Genant HK, Eyre DR, Survill TT, Ventura JN, DeBrock J, Ricerca E, Chesnut CH. (1993). The effect of short term treatment with alendronate on vertebral density and biochemical markers of bone remodeling in early postmenopausal women. J Clin Endocrinol Metab.
144 Hasling C, Charles P, Jensen FT, Mosekilde L. (1994). A comparison of the effects of oestrogen/progestogen, high-dose oral calcium, intermittent cyclic etidronate and an ADFR regime on calcium kinetics and bone mass in postmenopausal women with spinal osteoporosis. Osteoporos Int.
145 Haworth CS, Selby PL, Adams JE, Mawer EB, Horrocks AW, Webb AK. (2001). Effect of intravenous pamidronate on bone mineral density in adults with cystic fibrosis. Thorax.
146 Haworth CS, Selby PL, Webb AK, Mawer EB, Adams JE, Freemont TJ. (1998). Severe bone pain after intravenous pamidronate in adult patients with cystic fibrosis. Lancet.
147 Heaney RP, Saville PD. (1976). Etidronate disodium in postmenopausal osteoporosis. Clin Pharmacol Ther.
148 Heath DA, Bullivant BG, Boiven C, Balena R. (2000). The effects of cyclical etidronate on early postmenopausal bone loss: an open, randomized controlled study. J Clin Densitom.
149 Heikkinen J, Vaheri R, Timonen U. (2006). A 10-year follow-up of postmenopausal women on long-term continuous combined hormone replacement therapy: update of safety and quality-of-life findings. J Br Menopause Soc.
150 Heikkinen JE, Selander KS, Laitinen K, Arnala I, Vaananen HK. (1997). Short-term intravenous bisphosphonates in prevention of postmenopausal bone loss. J Bone Miner Res.
151 Hendrix SL, Wassertheil-Smoller S, Johnson KC, Howard BV, Kooperberg C, Rossouw JE, Trevisan M, Aragaki A, Baird AE, Bray PF, Buring JE, Criqui MH, Herrington D, Lynch JK, Rapp SR, Torner J. (2006). Effects of conjugated equine estrogen on stroke in the Women's Health Initiative. Circulation.
152 Hernandez E, Valera R, Alonzo E, Bajares-Lilue M, Carlini R, Capriles F, Martinis R, Bellorin-Font E, Weisinger JR. (2003). Effects of raloxifene on bone metabolism and serum lipids in postmenopausal women on chronic hemodialysis. Kidney International.
153 Herrera JA, Sarabia MO, Gonzalez MM. (1999). Effects of treatment with bisphosphonates on gastrointestinal and esophageal mucosa in patients with osteoporosis: Pamidronate versus alendronate. Current Therapeutic Research, Clinical & Experimental.
154 Ho AY, Kung AW. (2005). Efficacy and tolerability of alendronate once weekly in Asian postmenopausal osteoporotic women. Ann Pharmacother.
155 Hochberg MC, Ross PD, Black D, Cummings SR, Genant HK, Nevitt MC, Barrett-Connor E, Musliner T, Thompson D. (1999). Larger increases in bone mineral density during alendronate therapy are associated with a lower risk of new vertebral fractures in women with postmenopausal osteoporosis. Fracture Intervention Trial Research Group. Arthritis Rheum.
156 Hodsman AB, Fraher LJ. (1990). Biochemical responses to sequential human parathyroid hormone (1–38) and calcitonin in osteoporotic patients. Bone and Mineral.
157 Hodsman AB, Kisiel M, Adachi JD, Fraher LJ, Watson PH. (2000). Histomorphometric evidence for increased bone turnover without change in cortical thickness or porosity after 2 years of cyclical hPTH(1–34) therapy in women with severe osteoporosis. Bone.
158 Hodsman AB, Steer BM, Fraher LJ, Drost DJ. (1991). Bone densitometric and histomorphometric responses to sequential human parathyroid hormone (1–38) and salmon calcitonin in osteoporotic patients. Bone and Mineral.
159 Holloway L, Kohlmeier L, Kent K, Marcus R. (1997). Skeletal effects of cyclic recombinant human growth hormone and salmon calcitonin in osteopenic postmenopausal women. J Clin Endocrinol Metab.
160 Horwitz MJ, Tedesco MB, Gundberg C, Garcia-Ocana A, Stewart AF. (2003). Short-term, high-dose parathyroid hormone-related protein as a skeletal anabolic agent for the treatment of postmenopausal osteoporosis. J Clin Endocrinol Metab.
161 Howell SJ, Radford JA, Adams JE, Smets EM, Warburton R, Shalet SM. (2001). Randomized placebo-controlled trial of testosterone replacement in men with mild Leydig cell insufficiency following cytotoxic chemotherapy. Clinical Endocrinology.
162 Hsia J, Criqui MH, Rodabough RJ, Langer RD, Resnick HE, Phillips LS, Allison M, Bonds DE, Masaki K, Caralis P, Kotchen JM. (2004). Estrogen plus progestin and the risk of peripheral arterial disease: the Women's Health Initiative. Circulation.
163 Hsia J, Langer RD, Manson JE, Kuller L, Johnson KC, Hendrix SL, Pettinger M, Heckbert SR, Greep N, Crawford S, Eaton CB, Kostis JB, Caralis P, Prentice R. (2006). Conjugated equine estrogens and coronary heart disease: the Women's Health Initiative. Arch Intern Med.
164 Huusko TM, Karppi P, Kautiainen H, Suominen H, Avikainen V, Sulkava R. (2002). Randomized, double-blind, clinically controlled trial of intranasal calcitonin treatment in patients with hip fracture. Calcif Tissue Int.
165 Hwang JS, Tu ST, Yang TS, Chen JF, Wang CJ, Tsai KS. (2006). Teriparatide vs. calcitonin in the treatment of Asian postmenopausal women with established osteoporosis. Osteoporos Int.
166 Ilter E, Karalok H, Tufekci EC, Batur O. (2006). Efficacy and acceptability of risedronate 5 mg daily compared with 35 mg once weekly for the treatment of postmenopausal osteoporosis. Climacteric.
167 Jackson RD, LaCroix AZ, Cauley JA, McGowan J. (2003). The Women's Health Initiative calcium-vitamin D trial: overview and baseline characteristics of participants. Ann Epidemiol.
168 Jeffery JR, Leslie WD, Karpinski ME, Nickerson PW, Rush DN. (2003). Prevalence and treatment of decreased bone density in renal transplant recipients: a randomized prospective trial of calcitriol versus alendronate. Transplantation.
169 Jeffrey J, Leslie W, Karpinski M, Nickerson P, Rush D. (2003). Prevalence and treatment of decreased bone density in renal transplant recipients: a randomized prospective trial of calcitriol versus alendronate. Transplantation.
170 Jensen J, Christiansen C, Rodbro P. (1985). Cigarette smoking, serum estrogens, and bone loss during hormone-replacement therapy early after menopause. N Engl J Med.
171 Jodar E, Munoz-Torres M, Escobar-Jimenez F, Quesada M, Luna JD, Olea N. (1997). Antiresorptive therapy in hyperthyroid patients: longitudinal changes in bone and mineral metabolism. The Journal of Clinical Endocrinology and Metabolism.
172 Johnell O, Scheele WH, Lu Y, Reginster JY, Need AG, Seeman E. (2002). Additive effects of raloxifene and alendronate on bone density and biochemical markers of bone remodeling in postmenopausal women with osteoporosis. J Clin Endocrinol Metab.
173 Johnston, C. C. Jr; Bjarnason, N. H.; Cohen, F. J.; Shah, A.; Lindsay, R.; Mitlak, B. H.; Huster, W.; Draper, M. W.; Harper, K. D.; Heath, H. 3rd; Gennari, C.; Christiansen, C.; Arnaud, C. D., and Delmas, P. D. Long-term effects of raloxifene on bone mineral density, bone turnover, and serum lipid levels in early postmenopausal women: three-year data from 2 double-blind, randomized, placebo-controlled trials. Arch Intern Med. 2000 Dec 11–2000 Dec 25; 160(22):3444–50. Rec #: 1075
174 Jolly, E. E.; Bjarnason, N. H.; Neven, P.; Plouffe, L. Jr; Johnston, C. C. Jr; Watts, S. D.; Arnaud, C. D.; Mason, T. M.; Crans, G.; Akers, R., and Draper, M. W. Prevention of osteoporosis and uterine effects in postmenopausal women taking raloxifene for 5 years. Menopause. 2003 Jul–2003 Aug 31; 10(4):337–44. Rec #: 1403
175 Kapetanos G, Symeonides PP, Dimitriou C, Karakatsanis K, Potoupnis M. (1997). A double blind study of intranasal calcitonin for established postmenopausal osteoporosis. Acta Orthop Scand Suppl.
176 Kasayama S, Fujita M, Goya K, Yamamoto H, Fujita K, Morimoto Y, Kawase I, Miyatake A. (2005). Effects of alendronate on bone mineral density and bone metabolic markers in postmenopausal asthmatic women treated with inhaled corticosteroids. Metabolism.
177 Kendler D, Kung AW, Fuleihan Gel-H, Gonzalez Gonzalez JG, Gaines KA, Verbruggen N, Melton ME. (2004). Patients with osteoporosis prefer once weekly to once daily dosing with alendronate. Maturitas.
178 Kenny AM, Prestwood KM, Gruman CA, Marcello KM, Raisz LG. (2001). Effects of transdermal testosterone on bone and muscle in older men with low bioavailable testosterone levels. The Journals of Gerontology Series A, Biological Sciences and Medical Sciences.
179 Kikuchi, Y.; Imakiire, T.; Yamada, M.; Saigusa, T.; Hyodo, T.; Kushiyama, T.; Higashi, K.; Hyodo, N.; Yamamoto, K.; Suzuki, S., and Miura, S. Effect of risedronate on high-dose corticosteroid-induced bone loss in patients with glomerular disease. Nephrol Dial Transplant. 2006 Oct 13. Rec #: 3542
180 Kitatani K, Nakatsuka K, Naka H, Miki T, Morii H, Nishizawa Y. (2003). Clinical usefulness of measurements of urinary deoxypyridinoline (DPD) in patients with postmenopausal osteoporosis receiving intermittent cyclical etidronate: advantage of free form of DPD over total DPD in predicting treatment efficacy. Journal of Bone and Mineral Metabolism.
181 Koc M, Tuglular S, Arikan H, Ozener C, Akoglu E. (2002). Alendronate increases bone mineral density in long-term renal transplant recipients. Transplantation Proceedings.
182 Koc M, Tuglular S, Arikan H, Ozener C, Akoglu E. (2002). Alendronate increases bone mineral density in long-term renal transplant recipients. Transplant Proc.
183 Kollerup G, Hermann AP, Brixen K, Lindblad BE, Mosekilde L, Sorensen OH. (1994). Effects of salmon calcitonin suppositories on bone mass and turnover in established osteoporosis. Calcif Tissue Int.
184 Kotaniemi A, Piirainen H, Paimela L, Leirisalo-Repo M, Uoti-Reilama K, Lahdentausta P, Ruotsalainen P, Kataja M, Vaisanen E, Kurki P. (1996). Is continuous intranasal salmon calcitonin effective in treating axial bone loss in patients with active rheumatoid arthritis receiving low dose glucocorticoid therapy?. J Rheumatol.
185 Kress BC, Mizrahi IA, Armour KW, Marcus R, Emkey RD, Santora AC. (1999). Use of bone alkaline phosphatase to monitor alendronate therapy in individual postmenopausal osteoporotic women. Clin Chem.
186 Kristensen B, Ejlertsen B, Dalgaard P, Larsen L, Holmegaard SN, Transbol I, Mouridsen HT. (1994). Tamoxifen and bone metabolism in postmenopausal low-risk breast cancer patients: a randomized study. Journal of Clinical Oncology : Official Journal of the American Society of Clinical Oncology.
187 Kung AW, Chao HT, Huang KE, Need AG, Taechakraichana N, Loh FH, Gonzaga F, Sriram U, Ismail NM, Farooqi A, Rachman IA, Crans GG, Wong M, Thiebaud D. (2003). Efficacy and safety of raloxifene 60 milligrams/day in postmenopausal Asian women. J Clin Endocrinol Metab.
188 Kung AW, Pasion EG, Sofiyan M, Lau EM, Tay BK, Lam KS, Wilawan K, Ongphiphadhanakul B, Thiebaud D. (2006). A comparison of teriparatide and calcitonin therapy in postmenopausal Asian women with osteoporosis: a 6-month study. Curr Med Res Opin.
189 Kung AW, Yeung SS. (1996). Prevention of bone loss induced by thyroxine suppressive therapy in postmenopausal women: the effect of calcium and calcitonin. The Journal of Clinical Endocrinology and Metabolism.
190 Kung AW, Yeung SS, Chu LW. (2000). The efficacy and tolerability of alendronate in postmenopausal osteoporotic Chinese women: a randomized placebo-controlled study. Calcif Tissue Int.
191 Lakatos P, Nagy Z, Kiss L, Horvath C, Takacs I, Foldes J, Speer G, Bossanyi A. (2000). Prevention of corticosteroid-induced osteoporosis by alfacalcidol. Z Rheumatol.
192 Lane NE, Sanchez S, Genant HK, Jenkins DK, Arnaud CD. (2000). Short-term increases in bone turnover markers predict parathyroid hormone-induced spinal bone mineral density gains in postmenopausal women with glucocorticoid-induced osteoporosis. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
193 Lasco A, Gaudio A, Morabito N, Previti M, Mileto A, Frisina N, Cucinotta D. (2004). Effects of a long-term treatment with raloxifene on insulin sensitivity in postmenopausal women. Diabetologia.
194 Lau EM, Woo J, Chan YH, Griffith J. (2000). Alendronate prevents bone loss in Chinese women with osteoporosis. Bone.
195 Lau EM, Woo J, Chan YH, Li M. (2001). Alendronate for the prevention of bone loss in patients on inhaled steroid therapy. Bone.
196 Lees B, Garland SW, Walton C, Ross D, Whitehead MI, Stevenson JC. (1996). Role of oral pamidronate in preventing bone loss in postmenopausal women. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
197 Leung JY, Ho AY, Ip TP, Lee G, Kung AW. (2005). The efficacy and tolerability of risedronate on bone mineral density and bone turnover markers in osteoporotic Chinese women: a randomized placebo-controlled study. Bone.
198 Lindsay, R.; Gallagher, J. C.; Kleerekoper, M., and Pickar, J. H. Effect of lower doses of conjugated equine estrogens with and without medroxyprogesterone acetate on bone in early postmenopausal women. JAMA. 2002 May 22–2002 May 29; 287(20):2668–76. Rec #: 1033
199 Love RR, Mazess RB, Barden HS, Epstein S, Newcomb PA, Jordan VC, Carbone PP, DeMets DL. (1992). Effects of tamoxifen on bone mineral density in postmenopausal women with breast cancer. N Engl J Med.
200 Lufkin EG, Argueta R, Whitaker MD, Cameron AL, Wong VH, Egan KS, O'Fallon WM, Riggs BL. (1994). Pamidronate: an unrecognized problem in gastrointestinal tolerability. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
201 Lyritis GP, Ioannidis GV, Karachalios T, Roidis N, Kataxaki E, Papaioannou N, Kaloudis J, Galanos A. (1999). Analgesic effect of salmon calcitonin suppositories in patients with acute pain due to recent osteoporotic vertebral crush fractures: a prospective double-blind, randomized, placebo-controlled clinical study. The Clinical Journal of Pain.
202 Lyritis GP, Paspati I, Karachalios T, Ioakimidis D, Skarantavos G, Lyritis PG. (1997). Pain relief from nasal salmon calcitonin in osteoporotic vertebral crush fractures. A double blind, placebo-controlled clinical study. Acta Orthop Scand Suppl.
203 Mallmin H, Ljunghall S, Larsson K, Lindh E. (1991). Short-term effects of pamidronate on biochemical markers of bone metabolism in osteoporosis—a placebo-controlled dose-finding study. Upsala Journal of Medical Sciences.
204 Mango D, Ricci S, Manna P, Natili G, Dell'Acqua S. (1993). Preventive treatment of cortical bone loss with salmon nasal calcitonin in early postmenopausal women. Minerva Endocrinol.
205 Manson JE, Hsia J, Johnson KC, Rossouw JE, Assaf AR, Lasser NL, Trevisan M, Black HR, Heckbert SR, Detrano R, Strickland OL, Wong ND, Crouse JR, Stein E, Cushman M. (2003). Estrogen plus progestin and the risk of coronary heart disease. N Engl J Med.
206 Marttunen MB, Hietanen P, Tiitinen A, Ylikorkala O. (1998). Comparison of effects of tamoxifen and toremifene on bone biochemistry and bone mineral density in postmenopausal breast cancer patients. J Clin Endocrinol Metab.
207 Mastaglia SR, Mautalen CA, Parisi MS, Oliveri B. (2006). Vitamin D2 dose required to rapidly increase 25OHD levels in osteoporotic women. Eur J Clin Nutr.
208 Masud T, Mulcahy B, Thompson AV, Donnelly S, Keen RW, Doyle DV, Spector TD. (1998). Effects of cyclical etidronate combined with calcitriol versus cyclical etidronate alone on spine and femoral neck bone mineral density in postmenopausal osteoporotic women. Ann Rheum Dis.
209 McClung M, Clemmesen B, Daifotis A, Gilchrist NL, Eisman J, Weinstein RS, Fuleihan Gel-H, Reda C, Yates AJ, Ravn P. (1998). Alendronate prevents postmenopausal bone loss in women without osteoporosis. A double-blind, randomized, controlled trial. Alendronate Osteoporosis Prevention Study Group. Annals of Internal Medicine.
210 McClung, M. R.; San Martin, J.; Miller, P. D.; Civitelli, R.; Bandeira, F.; Omizo, M.; Donley, D. W.; Dalsky, G. P., and Eriksen, E. F. Opposite bone remodeling effects of teriparatide and alendronate in increasing bone mass. Arch Intern Med. 2005 Aug 8–2005 Aug 22; 165(15):1762–8. Rec #: 2767
211 McClung MR, Wasnich RD, Recker R, Cauley JA, Chesnut CH, Ensrud KE, Burdeska A, Mills T. (2004). Oral daily ibandronate prevents bone loss in early postmenopausal women without osteoporosis. J Bone Miner Res.
212 Melis GB, Cagnacci A, Bruni V, Falsetti L, Jasonni VM, Nappi C, Polatti F, Volpe A. (1996). Salmon calcitonin plus intravaginal estriol: An effective treatment for the menopause. Maturitas.
213 Merza Z, Blumsohn A, Mah PM, Meads DM, McKenna SP, Wylie K, Eastell R, Wu F, Ross RJ. (2006). Double-blind placebo-controlled study of testosterone patch therapy on bone turnover in men with borderline hypogonadism. Int J Androl.
214 Meschia M, Brincat M, Barbacini P, Crossignani PG, Albisetti W. (1993). A clinical trial on the effects of a combination of elcatonin (carbocalcitonin) and conjugated estrogens on vertebral bone mass in early postmenopausal women. Calcif Tissue Int.
215 Meunier PJ, Vignot E, Garnero P, Confavreux E, Paris E, Liu-Leage S, Sarkar S, Liu T, Wong M, Draper MW. (1999). Treatment of postmenopausal women with osteoporosis or low bone density with raloxifene. Raloxifene Study Group. Osteoporos Int.
216 Meunier PJ, Vignot E, Garnero, P., Confavreux E, Paris E, Sarkar S, et al. (1998). Postmenopausal women with osteoporosis: effects of raloxifine on bone mineral denisty in the hip and lumbar spine [abstract]. Bone.
217 Mikati MA, Dib L, Yamout B, Sawaya R, Rahi AC, Fuleihan Gel-H. (2006). Two randomized vitamin D trials in ambulatory patients on anticonvulsants: impact on bone. Neurology.
218 Miller PD, Shergy WJ, Body JJ, Chen P, Rohe ME, Krege JH. (2005). Longterm reduction of back pain risk in women with osteoporosis treated with teriparatide compared with alendronate. J Rheumatol.
219 Miller PD, Woodson G, Licata AA, Ettinger MP, Mako B, Smith ME, Wang L, Yates SJ, Melton ME, Palmisano JJ. (2000). Rechallenge of patients who had discontinued alendronate therapy because of upper gastrointestinal symptoms. Clinical Therapeutics.
220 Miller RG. (1969). The treatment of osteoporosis. A report of a double blind clinical therapeutic trial. Gerontol Clin (Basel).
221 Milliken LA, Going SB, Houtkooper LB, Flint-Wagner HG, Figueroa A, Metcalfe LL, Blew RM, Sharp SC, Lohman TG. (2003). Effects of exercise training on bone remodeling, insulin-like growth factors, and bone mineral density in postmenopausal women with and without hormone replacement therapy. Calcif Tissue Int.
222 Mizunuma H, Okano H, Soda M, Kagami I, Miyamoto S, Tokizawa T, Honjo S, Ibuki Y. (1997). Prevention of postmenopausal bone loss with minimal uterine bleeding using low dose continuous estrogen/progestin therapy: a 2-year prospective study. Maturitas.
223 Mizunuma H, Shiraki M, Shintani M, Gorai I, Makita K, Itoga S, Mochizuki Y, Mogi H, Iwaoki Y, Kosha S, Yasui T, Ishihara O, Kurabayashi T, Kasuga Y, Hayashi K. (2006). Randomized trial comparing low-dose hormone replacement therapy and HRT plus 1alpha-OH-vitamin D3 (alfacalcidol) for treatment of postmenopausal bone loss. J Bone Miner Metab.
224 Mondy K, Powderly WG, Claxton SA, Yarasheski KH, Royal M, Stoneman JS, Hoffmann ME, Tebas P. (2005). Alendronate, vitamin D, and calcium for the treatment of osteopenia/osteoporosis associated with HIV infection. J Acquir Immune Defic Syndr.
225 Morabito N, Lasco A, Gaudio A, Crisafulli A, Di Pietro C, Meo A, Frisina N. (2002). Bisphosphonates in the treatment of thalassemia-induced osteoporosis. Osteoporos Int.
226 Moran de Brito CM, Battistella LR, Saito ET, Sakamoto H. (2005). Effect of alendronate on bone mineral density in spinal cord injury patients: a pilot study. Spinal Cord.
227 Nakayamada S, Okada Y, Saito K, Tanaka Y. (2004). Etidronate prevents high dose glucocorticoid induced bone loss in premenopausal individuals with systemic autoimmune diseases. The Journal of Rheumatology.
228 Nam JH, Moon JI, Chung SS, Kim SI, Park KI, Song YD, Kim KR, Lee HC, Huh K, Lim SK. (2000). Pamidronate and calcitriol trial for the prevention of early bone loss after renal transplantation. Transplant Proc.
229 Neele SJ, Evertz R, De Valk-De Roo G, Roos JC, Netelenbos JC. (2002). Effect of 1 year of discontinuation of raloxifene or estrogen therapy on bone mineral density after 5 years of treatment in healthy postmenopausal women. Bone.
230 Negredo E, Martinez-Lopez E, Paredes R, Rosales J, Perez-Alvarez N, Holgado S, Gel S, del Rio L, Tena X, Rey-Joly C, Clotet B. (2005). Reversal of HIV-1-associated osteoporosis with once-weekly alendronate. AIDS.
231 Neven P, Lunde T, Benedetti-Panici P, Tiitinen A, Marinescu B, de Villiers T, Hillard T, Cano A, Peer E, Quail D, Nickelsen T. (2003). A multicentre randomised trial to compare uterine safety of raloxifene with a continuous combined hormone replacement therapy containing oestradiol and norethisterone acetate. BJOG.
232 Neven P, Quail D. Levrier M. Aguas F. The HS De Geyter C. Glant MD Beck H. Bosio-LeGoux B. Schmitt H. Hottgenroth A. Nickelsen T. Uterine effects of estrogen plus progestin therapy and raloxifene: adjudicated results from the EURALOX study. Obstetrics and Gynecology. 2004; 103(5 Pt 1):881–91. Rec #: 1315
233 Ng HT, Chang SP, Yang TS, Cho MP, Wei TC. (1993). Estradiol administered in a percutaneous gel for the prevention of postmenopausal bone loss. Asia Oceania J Obstet Gynaecol.
234 Nickelsen T, Lufkin EG, Riggs BL, Cox DA, Crook TH. (1999). Raloxifene hydrochloride, a selective estrogen receptor modulator: safety assessment of effects on cognitive function and mood in postmenopausal women. Psychoneuroendocrinology.
235 Notelovitz, M.; John, V. A., and Good, W. R. Effectiveness of Alora estradiol matrix transdermal delivery system in improving lumbar bone mineral density in healthy, postmenopausal women. Menopause. 2002 Sep–2002 Oct 31; 9(5):343–53. Rec #: 2904
236 Ongphiphadhanakul B, Piaseu N, Chailurkit L, Rajatanavin R. (1998). Suppression of bone resorption in early postmenopausal women by intranasal salmon calcitonin in relation to dosage and basal bone turnover. Calcif Tissue Int.
237 Orr-Walker B, Wattie DJ, Evans MC, Reid IR. (1997). Effects of prolonged bisphosphonate therapy and its discontinuation on bone mineral density in post-menopausal osteoporosis. Clin Endocrinol (Oxf).
238 Ott SM, Oleksik A, Lu Y, Harper K, Lips P. (2002). Bone histomorphometric and biochemical marker results of a 2-year placebo-controlled trial of raloxifene in postmenopausal women. J Bone Miner Res.
239 Overgaard K. (1994). Effect of intranasal salmon calcitonin therapy on bone mass and bone turnover in early postmenopausal women: a dose-response study. Calcif Tissue Int.
240 Overgaard, K.; Lindsay, R., and Christiansen, C. Patient responsiveness to calcitonin salmon nasal spray: a subanalysis of a 2-year study. Clin Ther. 1995 Jul–1995 Aug 31; 17(4):680–5. Rec #: 1761
241 Palomba S, Orio F, Colao A, di Carlo C, Sena T, Lombardi G, Zullo F, Mastrantonio P. (2002). Effect of estrogen replacement plus low-dose alendronate treatment on bone density in surgically postmenopausal women with osteoporosis. J Clin Endocrinol Metab.
242 Palomba S, Orio F, Morelli M, Russo T, Pellicano M, Nappi C, Mastrantonio P, Lombardi G, Colao A, Zullo F. (2002). Raloxifene administration in women treated with gonadotropin-releasing hormone agonist for uterine leiomyomas: effects on bone metabolism. J Clin Endocrinol Metab.
243 ---. Raloxifene administration in women treated with gonadotropin-releasing hormone agonist for uterine leiomyomas: effects on bone metabolism. J Clin Endocrinol Metab. 2002 Oct; 87(10):4476–81. Rec #: 1507
244 Palomba S, Orio F, Russo T, Colao A, Lombardi G, Zullo F. (2004). Dose reduction and discontinuation of alendronate in postmenopausal osteoporotic women who were receiving estrogen therapy. Fertility and Sterility.
245 Paschalis EP, Glass EV, Donley DW, Eriksen EF. (2005). Bone mineral and collagen quality in iliac crest biopsies of patients given teriparatide: new results from the fracture prevention trial. J Clin Endocrinol Metab.
246 Patel R, Blake GM, Herd RJ, Fogelman I. (1997). The effect of weight change on DXA scans in a 2-year trial of etidronate therapy. Calcified Tissue International.
247 Pearson EG, Nance PW, Leslie WD, Ludwig S. (1997). Cyclical etidronate: its effect on bone density in patients with acute spinal cord injury. Archives of Physical Medicine and Rehabilitation.
248 Pereda CA, Hannon RA, Naylor KE, Eastell R. (2002). The impact of subcutaneous oestradiol implants on biochemical markers of bone turnover and bone mineral density in postmenopausal women. BJOG : an International Journal of Obstetrics and Gynaecology.
249 Peretz A, Siderova V, Body JJ, Dumon JC, Rozenberg S, Fellemans C, Fuss M, Bergmann P. (2003). Response to alendronate in osteoporotic women previously treated with pamidronate. Maturitas.
250 Perez-Jaraiz MD, Revilla M, Alvarez de los Heros JI, Villa LF, Rico H. (1996). Prophylaxis of osteoporosis with calcium, estrogens and/or eelcatonin: comparative longitudinal study of bone mass. Maturitas.
251 Perrone G, Galoppi P, Valente M, Capri O, D'Ubaldo C, Anelli G, Zichella L. (1992). Intranasal salmon calcitonin in postmenopausal osteoporosis: effect of different therapeutic regimens on vertebral and peripheral bone density. Gynecologic and Obstetric Investigation.
252 Pitt P, Li F, Bloom B, Todd P, Pack S, Hughes G, Moniz C. (1997). A double-blind placebo controlled study to determine the effects of intermittent cyclical etidronate on bone mineral density in patients on long term corticosteroid treatment. Bone.
253 Pivonello R, Faggiano A, Di Somma C, Klain M, Filippella M, Salvatore M, Lombardi G, Colao A. (1999). Effect of a short-term treatment with alendronate on bone density and bone markers in patients with central diabetes insipidus. The Journal of Clinical Endocrinology and Metabolism.
254 Pouilles JM, Tremollieres F, Roux C, Sebert JL, Alexandre C, Goldberg D, Treves R, Khalifa P, Duntze P, Horlait S, Delmas P, Kuntz D. (1997). Effects of cyclical etidronate therapy on bone loss in early postmenopausal women who are not undergoing hormonal replacement therapy. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
255 Powles TJ, Hickish T, Kanis JA, Tidy A, Ashley S. (1996). Effect of tamoxifen on bone mineral density measured by dual-energy x-ray absorptiometry in healthy premenopausal and postmenopausal women. J Clin Oncol.
256 Prestwood KM, Gunness M, Muchmore DB, Lu Y, Wong M, Raisz LG. (2000). A comparison of the effects of raloxifene and estrogen on bone in postmenopausal women. J Clin Endocrinol Metab.
257 Prince RL, Smith M, Dick IM, Price RI, Webb PG, Henderson NK, Harris MM. (1991). Prevention of postmenopausal osteoporosis. A comparative study of exercise, calcium supplementation, and hormone-replacement therapy. The New England Journal of Medicine.
258 Psimenou, E.; Konstantinidou, E.; Giapraka, N.; Marinaki, S.; Kostakis, A.; Stathakis, C. P., and Boletis, J. N. Randomised controlled study of calcitonine and etidronate in the treatment of osteoporosis in renal transplant patients. 2002. Rec #: 1346
259 Qureshi AM, Herd RJ, Blake GM, Fogelman I, Ralston SH. (2002). COLIA1 Sp1 polymorphism predicts response of femoral neck bone density to cyclical etidronate therapy. Calcified Tissue International.
260 Ravn P, Christensen JO, Baumann M, Clemmesen B. (1998). Changes in biochemical markers and bone mass after withdrawal of ibandronate treatment: prediction of bone mass changes during treatment. Bone.
261 Ravn P, Cizza G, Bjarnason NH, Thompson D, Daley M, Wasnich RD, McClung M, Hosking D, Yates AJ, Christiansen C. (1999). Low body mass index is an important risk factor for low bone mass and increased bone loss in early postmenopausal women. Early Postmenopausal Intervention Cohort (EPIC) study group. J Bone Miner Res.
262 Ravn P, Clemmesen B, Christiansen C. (1999). Biochemical markers can predict the response in bone mass during alendronate treatment in early postmenopausal women. Alendronate Osteoporosis Prevention Study Group. Bone.
263 Ravn P, Hosking D, Thompson D, Cizza G, Wasnich RD, McClung M, Yates AJ, Bjarnason NH, Christiansen C. (1999). Monitoring of alendronate treatment and prediction of effect on bone mass by biochemical markers in the early postmenopausal intervention cohort study. J Clin Endocrinol Metab.
264 Ravn P, Neugebauer G, Christiansen C. (2002). Association between pharmacokinetics of oral ibandronate and clinical response in bone mass and bone turnover in women with postmenopausal osteoporosis. Bone.
265 Ravn P, Thompson DE, Ross PD, Christiansen C. (2003). Biochemical markers for prediction of 4-year response in bone mass during bisphosphonate treatment for prevention of postmenopausal osteoporosis. Bone.
266 Ravn P, Weiss SR, Rodriguez-Portales JA, McClung MR, Wasnich RD, Gilchrist NL, Sambrook P, Fogelman I, Krupa D, Yates AJ, Daifotis A, Fuleihan GE. (2000). Alendronate in early postmenopausal women: effects on bone mass during long-term treatment and after withdrawal. Alendronate Osteoporosis Prevention Study Group. The Journal of Clinical Endocrinology and Metabolism.
267 Recker R, Lips P, Felsenberg D, Lippuner K, Benhamou L, Hawkins F, Delmas PD, Rosen C, Emkey R, Salzmann G, He W, Santora AC. (2006). Alendronate with and without cholecalciferol for osteoporosis: results of a 15-week randomized controlled trial. Curr Med Res Opin.
268 Recker RR, Weinstein RS, Chesnut CH, Schimmer RC, Mahoney P, Hughes C, Bonvoisin B, Meunier PJ. (2004). Histomorphometric evaluation of daily and intermittent oral ibandronate in women with postmenopausal osteoporosis: results from the BONE study. Osteoporos Int.
269 Recker RR, Weinsyein RS, Chestnut CH, Schimmer RC, Mahoney P, Hughes C, Bonvision B, Meunier PJ. (2004). Histomor-phometric evaluation of daily and intermittent oral ibandronate in women with postmenopausal osteoporosis: results from the BONE study. Osteoporosis Int.
270 Reeve J, Mitchell A, Tellez M, Hulme P, Green JR, Wardley-Smith B, Mitchell R. (2001). Treatment with parathyroid peptides and estrogen replacement for severe postmenopausal vertebral osteoporosis: prediction of long-term responses in spine and femur. Journal of Bone and Mineral Metabolism.
271 Reginster JY, Denis D, Albert A, Deroisy R, Lecart MP, Fontaine MA, Lambelin P, Franchimont P. (1987). 1-Year controlled randomised trial of prevention of early postmenopausal bone loss by intranasal calcitonin. Lancet.
272 Reginster JY, Denis D, Deroisy R, Lecart MP, De Longueville M, Zegels B, Sarlet N, Noirfalisse P, Franchimont P. (1994). Long-term (3 years) prevention of trabecular postmenopausal bone loss with low-dose intermittent nasal salmon calcitonin. J Bone Miner Res.
273 Reginster JY, Deroisy R, Lecart MP, Sarlet N, Zegels B, Jupsin I, de Longueville M, Franchimont P. (1995). A double-blind, placebo-controlled, dose-finding trial of intermittent nasal salmon calcitonin for prevention of postmenopausal lumbar spine bone loss. Am J Med.
274 Reginster JY, Jupsin I, Deroisy R, Biquet I, Franchimont N, Franchimont P. (1995). Prevention of postmenopausal bone loss by rectal calcitonin. Calcif Tissue Int.
275 Reginster JY, Meurmans L, Deroisy R, Jupsin I, Biquet I, Albert A, Franchimont P. (1994). A 5-year controlled randomized study of prevention of postmenopausal trabecular bone loss with nasal salmon calcitonin and calcium. European Journal of Clinical Investigation.
276 Reginster JY, Wilson KM, Dumont E, Bonvoisin B, Barrett J. (2005). Monthly oral ibandronate is well tolerated and efficacious in postmenopausal women: results from the monthly oral pilot study. J Clin Endocrinol Metab.
277 Rehman Q, Lang TF, Arnaud CD, Modin GW, Lane NE. (2003). Daily treatment with parathyroid hormone is associated with an increase in vertebral cross-sectional area in postmenopausal women with glucocorticoid-induced osteoporosis. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
278 Reid IR, King AR, Alexander CJ, Ibbertson HK. (1988). Prevention of steroid-induced osteoporosis with (3-amino-1-hydroxypropylidene)-1,1-bisphosphonate (APD). Lancet.
279 Rhee Y, Kang M, Min Y, Byun D, Chung Y, Ahn C, Baek K, Mok J, Kim D, Kim D, Kim H, Kim Y, Myoung S, Kim D, Lim SK. (2006). Effects of a combined alendronate and calcitriol agent (Maxmarvil(R)) on bone metabolism in Korean postmenopausal women: a multicenter, double-blind, randomized, placebo-controlled study. Osteoporos Int.
280 Riis BJ, Ise J, von Stein T, Bagger Y, Christiansen C. (2001). Ibandronate: a comparison of oral daily dosing versus intermittent dosing in postmenopausal osteoporosis. J Bone Miner Res.
281 Ripps BA, VanGilder K, Minhas B, Welford M, Mamish Z. (2003). Alendronate for the prevention of bone mineral loss during gonadotropin-releasing hormone agonist therapy. The Journal of Reproductive Medicine.
282 Rosen HN, Moses AC, Garber J, Ross DS, Lee SL, Ferguson L, Chen V, Lee K, Greenspan SL. (1998). Randomized trial of pamidronate in patients with thyroid cancer: bone density is not reduced by suppressive doses of thyroxine, but is increased by cyclic intravenous pamidronate. The Journal of Clinical Endocrinology and Metabolism.
283 Rubin MR, Lee KH, McMahon DJ, Silverberg SJ. (2003). Raloxifene lowers serum calcium and markers of bone turnover in postmenopausal women with primary hyperparathyroidism. J Clin Endocrinol Metab.
284 Ryan PJ, Blake GM, Davie M, Haddaway M, Gibson T, Fogelman I. (2000). Intermittent oral disodium pamidronate in established osteoporosis: a 2 year double-masked placebo-controlled study of efficacy and safety. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
285 Saarto T, Blomqvist C, Valimaki M, Makela P, Sarna S, Elomaa I. (1997). Clodronate improves bone mineral density in post-menopausal breast cancer patients treated with adjuvant antioestrogens. British Journal of Cancer.
286 Sambrook PN, Geusens P, Ribot C, Solimano JA, Ferrer-Barriendos J, Gaines K, Verbruggen N, Melton ME. (2004). Alendronate produces greater effects than raloxifene on bone density and bone turnover in postmenopausal women with low bone density: results of EFFECT (Efficacy of FOSAMAX versus EVISTA Comparison Trial) International. Journal of Internal Medicine.
287 Sarioglu M, Tuzun C, Unlu Z, Tikiz C, Taneli F, Uyanik BS. (2006). Comparison of the effects of alendronate and risedronate on bone mineral density and bone turnover markers in postmenopausal osteoporosis. Rheumatol Int.
288 Schneider PF, Fischer M, Allolio B, Felsenberg D, Schroder U, Semler J, Ittner JR. (1999). Alendronate increases bone density and bone strength at the distal radius in postmenopausal women. Journal of Bone and Mineral Research : the Official Journal of the American Society for Bone and Mineral Research.
289 Schubert M, Bullmann C, Minnemann T, Reiners C, Krone W, Jockenhovel F. (2003). Osteoporosis in male hypogonadism: responses to androgen substitution differ among men with primary and secondary hypogonadism. Hormone Research.
290 Schwarz C, Mitterbauer C, Heinze G, Woloszczuk W, Haas M, Oberbauer R. (2004). Nonsustained effect of short-term bisphosphonate therapy on bone turnover three years after renal transplantation. Kidney International.
291 Sebba AI, Bonnick SL, Kagan R, Thompson DE, Skalky CS, Chen E, de Papp AE. (2004). Response to therapy with once-weekly alendronate 70 mg compared to once-weekly risedronate 35 mg in the treatment of postmenopausal osteoporosis. Curr Med Res Opin.
292 Shand B, Gilchrist N, Blackwell T, March R. (2002). The hemorheological effects of raloxifene in postmenopausal women with osteoporosis. Results of a 3-year placebo-controlled clinical trial. Clinical Hemorheology and Microcirculation.
293 Sharma RK, Jeloka T, Gupta A, Gupta S, Gulati S, Sharma AP, Kumar A, Bhandari M. (2003). Role of alendronate on post renal transplant osteoporosis: a randomized study. Nephrology Dialysis Transplantation.
294 Shiomi S, Nishiguchi S, Kurooka H, Tamori A, Habu D, Takeda T, Ochi H. (2002). Cyclical etidronate for treatment of osteopenia in patients with cirrhosis of the liver. Hepatol Res.
295 Shiraki M, Fukunaga M, Kushida K, Kishimoto H, Taketani Y, Minaguchi H, Inoue T, Morita R, Morii H, Yamamoto K, Ohashi Y, Orimo H. (2003). A double-blind dose-ranging study of risedronate in Japanese patients with osteoporosis (a study by the Risedronate Late Phase II Research Group). Osteoporos Int.
296 Shiraki M, Kushida K, Fukunaga M, Kishimoto H, Taga M, Nakamura T, Kaneda K, Minaguchi H, Inoue T, Morii H, Tomita A, Yamamoto K, Nagata Y, Nakashima M, Orimo H. (1999). A double-masked multicenter comparative study between alendronate and alfacalcidol in Japanese patients with osteoporosis. The Alendronate Phase III Osteoporosis Treatment Research Group. Osteoporos Int.
297 Siffledeen JS, Fedorak RN, Siminoski K, Jen H, Vaudan E, Abraham N, Steinhart H, Greenberg G. (2005). Randomized trial of etidronate plus calcium and vitamin D for treatment of low bone mineral density in Crohn's disease. Clin Gastroenterol Hepatol.
298 Simon JA, Lewiecki EM, Smith ME, Petruschke RA, Wang L, Palmisano JJ. (2002). Patient preference for once-weekly alendronate 70 mg versus once-daily alendronate 10 mg: a multicenter, randomized, open-label, crossover study. Clin Ther.
299 Skingle SJ, Crisp AJ. (1994). Increased bone density in patients on steroids with etidronate. Lancet.
300 Smith ML, Fogelman I, Hart DM, Scott E, Bevan J, Leggate I. (1989). Effect of etidronate disodium on bone turnover following surgical menopause. Calcif Tissue Int.
301 Smith MR, Eastham J, Gleason DM, Shasha D, Tchekmedyian S, Zinner N. (2003). Randomized controlled trial of zoledronic acid to prevent bone loss in men receiving androgen deprivation therapy for nonmetastatic prostate cancer. The Journal of Urology.
302 Smith MR, Fallon MA, Lee H, Finkelstein JS. (2004). Raloxifene to prevent gonadotropin-releasing hormone agonist-induced bone loss in men with prostate cancer: a randomized controlled trial. The Journal of Clinical Endocrinology and Metabolism.
303 Smith MR, McGovern FJ, Zietman AL, Fallon MA, Hayden DL, Schoenfeld DA, Kantoff PW, Finkelstein JS. (2001). Pamidronate to prevent bone loss during androgen-deprivation therapy for prostate cancer. The New England Journal of Medicine.
304 Snyder PJ, Peachey H, Hannoush P, Berlin JA, Loh L, Holmes JH, Dlewati A, Staley J, Santanna J, Kapoor SC, Attie MF, Haddad JG, Strom BL. (1999). Effect of testosterone treatment on bone mineral density in men over 65 years of age. J Clin Endocrinol Metab.
305 Srivastava AK, Libanati C, Hohmann O, Kriegman A, Baylink DJ. (2004). Acute effects of calcitonin nasal spray on serum C-telopeptide of type 1 collagen (CTx) levels in elderly osteopenic women with increased bone turnover. Calcif Tissue Int.
306 Stakkestad JA, Benevolenskaya LI, Stepan JJ, Skag A, Nordby A, Oefjord E, Burdeska A, Jonkanski I, Mahoney P. (2003). Intravenous ibandronate injections given every three months: a new treatment option to prevent bone loss in postmenopausal women. Ann Rheum Dis.
307 Stefanick ML, Anderson GL, Margolis KL, Hendrix SL, Rodabough RJ, Paskett ED, Lane DS, Hubbell FA, Assaf AR, Sarto GE, Schenken RS, Yasmeen S, Lessin L, Chlebowski RT. (2006). Effects of conjugated equine estrogens on breast cancer and mammography screening in postmenopausal women with hysterectomy. JAMA.
308 Steiniche T, Hasling C, Charles P, Eriksen EF, Melsen F, Mosekilde L. (1991). The effects of etidronate on trabecular bone remodeling in postmenopausal spinal osteoporosis: a randomized study comparing intermittent treatment and an ADFR regime. Bone.
309 Stepan J, Formankova J, Masatova A, Michalsky M, Rosenova Z. (1997). [Comparison of the effectiveness of 17-beta-estradiol and calcitonin in women with postmenopausal bone loss]. Casopis Lekaru Ceskych.
310 Stepan JJ, Vokrouhlicka J. (1999). Comparison of biochemical markers of bone remodelling in the assessment of the effects of alendronate on bone in postmenopausal osteoporosis. Clinica Chimica Acta; International Journal of Clinical Chemistry.
311 Stock JL, Bell NH, Chesnut CH, Ensrud KE, Genant HK, Harris ST, McClung MR, Singer FR, Yood RA, Pryor-Tillotson S, Wei L, Santora AC. (1997). Increments in bone mineral density of the lumbar spine and hip and suppression of bone turnover are maintained after discontinuation of alendronate in postmenopausal women. Am J Med.
312 Storm T, Steiniche T, Thamsborg G, Melsen F. (1993). Changes in bone histomorphometry after long-term treatment with intermittent, cyclic etidronate for postmenopausal osteoporosis. J Bone Miner Res.
313 Struijs A, Smals A, de Witte SA, Hackeng WH, Mulder H. (2000). Acute effects of etidronate on glucocorticoid-induced bone degradation. Rheumatology (Oxford, England).
314 Sverrisdottir A, Fornander T, Jacobsson H, von Schoultz E, Rutqvist LE. (2004). Bone mineral density among premenopausal women with early breast cancer in a randomized trial of adjuvant endocrine therapy. Journal of Clinical Oncology : Official Journal of the American Society of Clinical Oncology.
315 Tanko LB, Bagger YZ, Alexandersen P, Devogelaer JP, Reginster JY, Chick R, Olson M, Benmammar H, Mindeholm L, Azria M, Christiansen C. (2004). Safety and efficacy of a novel salmon calcitonin (sCT) technology-based oral formulation in healthy postmenopausal women: acute and 3-month effects on biomarkers of bone turnover. J Bone Miner Res.
316 Tanko LB, Felsenberg D, Czerwinski E, Burdeska A, Jonkanski I, Hughes C, Christiansen C. (2003). Oral weekly ibandronate prevents bone loss in postmenopausal women. Journal of Internal Medicine.
317 Tanko LB, McClung MR, Schimmer RC, Mahoney P, Christiansen C. (2003). The efficacy of 48-week oral ibandronate treatment in postmenopausal osteoporosis when taken 30 versus 60 minutes before breakfast. Bone.
318 Tanko LB, Mouritzen U, Lehmann HJ, Warming L, Moelgaard A, Christgau S, Qvist P, Baumann M, Wieczorek L, Hoyle N, Christiansen C. (2003). Oral ibandronate: changes in markers of bone turnover during adequately dosed continuous and weekly therapy and during different suboptimally dosed treatment regimens. Bone.
319 Tanko LB, Qin G, Alexandersen P, Bagger YZ, Christiansen C. (2005). Effective doses of ibandronate do not influence the 3-year progression of aortic calcification in elderly osteoporotic women. Osteoporos Int.
320 Tas N, Aricioglu A, Erbas D, Ozcan S. (2002). The effect of calcitonin treatment on plasma nitric oxide levels in post-menopausal osteoporotic patients. Cell Biochem Funct.
321 Tauchmanova L, Selleri C, Esposito M, Di Somma C, Orio F, Bifulco G, Palomba S, Lombardi G, Rotoli B, Colao A. (2003). Beneficial treatment with risedronate in long-term survivors after allogeneic stem cell transplantation for hematological malignancies. Osteoporos Int.
322 Tekeoglu I, Adak B, Budancamanak M, Demirel A, Ediz L. (2005). Comparison of cyclic and continuous calcitonin regimens in the treatment of postmenopausal osteoporosis. Rheumatol Int.
323 Thamsborg G, Jensen JE, Kollerup G, Hauge EM, Melsen F, Sorensen OH. (1996). Effect of nasal salmon calcitonin on bone remodeling and bone mass in postmenopausal osteoporosis. Bone.
324 Thamsborg G, Storm T, Sykulski R, Brinch E, Andersen NF, Holmegard SN, Soerensen OH. (1988). Intranasal calcitonin and prevention of postmenopausal bone loss. Lancet.
325 Thiebaud D, Burckhardt P, Kriegbaum H, Huss H, Mulder H, Juttmann JR, Schoter KH. (1997). Three monthly intravenous injections of ibandronate in the treatment of postmenopausal osteoporosis. Am J Med.
326 Tiitinen A, Nikander E, Hietanen P, Metsa-Heikkila M, Ylikorkala O. (2004). Changes in bone mineral density during and after 3 years' use of tamoxifen or toremifene. Maturitas.
327 Tiitinen A, Nikander E, Hietanen P, Metsa-Heikkila M, Ylikorkala O. (2004). Changes in bone mineral density during and after 3 years' use of tamoxifen or toremifene. Maturitas.
328 Tiras MB, Noyan V, Yildiz A, Biberoglu K. (2000). Comparison of different treatment modalities for postmenopausal patients with osteopenia: hormone replacement therapy, calcitonin and clodronate. Climacteric.
329 Tiras MB, Noyan V, Yildiz A, Yildirim M, Daya S. (2000). Effects of alendronate and hormone replacement therapy, alone or in combination, on bone mass in postmenopausal women with osteoporosis: a prospective, randomized study. Hum Reprod.
330 Tobias JH, Dalzell N, Pazianas M, Chambers TJ. (1997). Cyclical etidronate prevents spinal bone loss in early post-menopausal women. Br J Rheumatol.
331 Tsai KS, Yen ML, Pan HA, Wu MH, Cheng WC, Hsu SH, Yen BL, Huang KE. (2001). Raloxifene versus continuous combined estrogen/progestin therapy: densitometric and biochemical effects in healthy postmenopausal Taiwanese women. Osteoporos Int.
332 Tucci JR, Tonino RP, Emky RD, Peverly CA, Kher U, Santora AC. (1996). Effect of three years of oral alendronate treatment in postmenopausal women with osteoproris. Am J Med.
333 Uusi-Rasi K, Beck TJ, Semanick LM, Daphtary MM, Crans GG, Desaiah D, Harper KD. (2006). Structural effects of raloxifene on the proximal femur: results from the multiple outcomes of raloxifene evaluation trial. Osteoporos Int.
334 Uusi-Rasi K, Kannus P, Cheng S, Sievanen H, Pasanen M, Heinonen A, Nenonen A, Halleen J, Fuerst T, Genant H, Vuori I. (2003). Effect of alendronate and exercise on bone and physical performance of postmenopausal women: a randomized controlled trial. Bone.
335 Uusi-Rasi K, Semanick LM, Zanchetta JR, Bogado CE, Eriksen EF, Sato M, Beck TJ. (2005). Effects of teriparatide. Bone.
336 Uusi-Rasi K, Sievanen H, Heinonen A, Kannus P, Vuori I. (2004). Effect of discontinuation of alendronate treatment and exercise on bone mass and physical fitness: 15-month follow-up of a randomized, controlled trial. Bone.
337 Valero MA, Loinaz C, Larrodera L, Leon M, Moreno E, Hawkins F. (1995). Calcitonin and bisphosphonates treatment in bone loss after liver transplantation. Calcif Tissue Int.
338 van der Poest Clement E, van Engeland M, Ader H, Roos JC, Patka P, Lips P. (2002). Alendronate in the prevention of bone loss after a fracture of the lower leg. Journal of Bone and Mineral Research : the Official Journal of the American Society for Bone and Mineral Research.
339 Van Offel JF, Schuerwegh AJ, Bridts CH, Bracke PG, Stevens WJ, De Clerck LS. (2001). Influence of cyclic intravenous pamidronate on proinflammatory monocytic cytokine profiles and bone density in rheumatoid arthritis treated with low dose prednisolone and methotrexate. Clin Exp Rheumatol.
340 Vedi S, Ninkovic M, Garrahan NJ, Alexander GJ, Compston JE. (2002). Effects of a single infusion of pamidronate prior to liver transplantation: a bone histomorphometric study. Transplant International : Official Journal of the European Society for Organ Transplantation.
341 Vega E, Gonzalez D, Ghiringhelli G, Mautalen C. (1989). Acute effect of the intranasal administration of salmon calcitonin in osteoporotic women. Bone and Mineral.
342 von Tirpitz C, Klaus J, Steinkamp M, Hofbauer LC, Kratzer W, Mason R, Boehm BO, Adler G, Reinshagen M. (2003). Therapy of osteoporosis in patients with Crohn's disease: a randomized study comparing sodium fluoride and ibandronate. Alimentary Pharmacology & Therapeutics.
343 Wactawski-Wende J, Kotchen JM, Anderson GL, Assaf AR, Brunner RL, O'Sullivan MJ, Margolis KL, Ockene JK, Phillips L, Pottern L, Prentice RL, Robbins J, Rohan TE, Sarto GE, Sharma S, Stefanick ML, Van Horn L, Wallace RB, Whitlock E, Bassford T, Beresford SA, Black HR, Bonds DE, Brzyski RG, Caan B, Chlebowski RT, Cochrane B, Garland C, Gass M, Hays J, Heiss G, Hendrix SL, Howard BV, Hsia J, Hubbell FA, Jackson RD, Johnson KC, Judd H, Kooperberg CL, Kuller LH, LaCroix AZ, Lane DS, Langer RD, Lasser NL, Lewis CE, Limacher MC, Manson JE. (2006). Calcium plus vitamin D supplementation and the risk of colorectal cancer. N Engl J Med.
344 Wang C, Cunningham G, Dobs A, Iranmanesh A, Matsumoto AM, Snyder PJ, Weber T, Berman N, Hull L, Swerdloff RS. (2004). Long-term testosterone gel (AndroGel) treatment maintains beneficial effects on sexual function and mood, lean and fat mass, and bone mineral density in hypogonadal men. The Journal of Clinical Endocrinology and Metabolism.
345 Wang C, Swerdloff RS, Iranmanesh A, Dobs A, Snyder PJ, Cunningham G, Matsumoto AM, Weber T, Berman N. (2001). Effects of transdermal testosterone gel on bone turnover markers and bone mineral density in hypogonadal men. Clinical Endocrinology.
346 Wang WQ, Ip MS, Tsang KW, Lam KS. (1998). Antiresorptive therapy in asthmatic patients receiving high-dose inhaled steroids: a prospective study for 18 months. J Allergy Clin Immunol.
347 Wasnich RD, Ross PD, Thompson DE, Cizza G, Yates AJ. (1999). Skeletal benefits of two years of alendronate treatment are similar for early postmenopausal Asian and Caucasian women. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
348 Wasnich RD, Bagger YZ, Hosking DJ, McClung MR, Wu M, Mantz AM, Yates JJ, Ross PD, Alexandersen P, Ravn P, Christiansen C, Santora AC. (2004). Changes in bone density and turnover after alendronate or estrogen withdrawal. Menopause (New York, NY).
349 Wassertheil-Smoller S, Hendrix SL, Limacher M, Heiss G, Kooperberg C, Baird A, Kotchen T, Curb JD, Black H, Rossouw JE, Aragaki A, Safford M, Stein E, Laowattana S, Mysiw WJ. (2003). Effect of estrogen plus progestin on stroke in postmenopausal women: the Women's Health Initiative: a randomized trial. JAMA.
350 Watanabe Y, Ohshima H, Mizuno K, Sekiguchi C, Fukunaga M, Kohri K, Rittweger J, Felsenberg D, Matsumoto T, Nakamura T. (2004). Intravenous pamidronate prevents femoral bone loss and renal stone formation during 90-day bed rest. Journal of Bone and Mineral Research : the Official Journal of the American Society for Bone and Mineral Research.
351 Watts NB, Jenkins DK, Visor JM, Casal DC, Geusens P. (2001). Comparison of bone and total alkaline phosphatase and bone mineral density in postmenopausal osteoporotic women treated with alendronate. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
352 Watts, N. B.; Nolan, J. C.; Brennan, J. J., and Yang, H. M. Esterified estrogen therapy in postmenopausal women. Relationships of bone marker changes and plasma estradiol to BMD changes: a two-year study. Menopause. 2000 Nov–2000 Dec 31; 7(6):375–82. Rec #: 2924
353 Weaver CM, Teegarden D, Lyle RM, McCabe GP, McCabe LD, Proulx W, Kern M, Sedlock D, Anderson DD, Hillberry BM, Peacock M, Johnston CC. (2001). Impact of exercise on bone health and contraindication of oral contraceptive use in young women. Medicine and Science in Sports and Exercise.
354 Weinstein RS, Bone H, Tucci J, et al. (1994). Alendronate treatment of osteoporosis in elderly women. J Bone Miner Res.
355 Weinstein RS, Parfitt AM, Marcus R, Greenwald M, Crans G, Muchmore DB. (2003). Effects of raloxifene, hormone replacement therapy, and placebo on bone turnover in postmenopausal women. Osteoporos Int.
356 Wenstrup RJ, Bailey L, Grabowski GA, Moskovitz J, Oestreich AE, Wu W, Sun S. (2004). Gaucher disease: alendronate disodium improves bone mineral density in adults receiving enzyme therapy. Blood.
357 Wetmore JB, Benet LZ, Kleinstuck D, Frassetto L. (2005). Effects of short-term alendronate on bone mineral density in haemodialysis patients. Nephrology (Carlton).
358 Wimalawansa SJ. (1995). Combined therapy with estrogen and etidronate has an additive effect on bone mineral density in the hip and vertebrae: four-year randomized study. Am J Med.
359 Yaffe K, Krueger K, Sarkar S, Grady D, Barrett-Connor E, Cox DA, Nickelsen T. (2001). Cognitive function in postmenopausal women treated with raloxifene. The New England Journal of Medicine.
360 Yamaguchi K, Masuhara K, Yamasaki S, Nakai T, Fuji T. (2003). Cyclic therapy with etidronate has a therapeutic effect against local osteoporosis after cementless total hip arthroplasty. Bone.
361 Yang TS, Tsan SH, Chen CR, Chang SP, Yuan CC. (1998). Effects of alendronate on bone turnover markers in early postmenopausal women. Zhonghua Yi Xue Za Zhi (Taipei).
362 Yen ML, Yen BL, Jang MH, Hsu SH, Cheng WC, Tsai KS. (2000). Effects of alendronate on osteopenic postmenopausal Chinese women. Bone.
363 Yilmaz L, Ozoran K, Gunduz OH, Ucan H, Yucel M. (2000). Alendronate in rheumatoid arthritis patients treated with methotrexate and glucocorticoids. Rheumatology International.
364 Zanchetta JR, Bogado CE, Ferretti JL, Wang O, Wilson MG, Sato M, Gaich GA, Dalsky GP, Myers SL. (2003). Effects of teriparatide. Journal of Bone & Mineral Research.
365 Zehnder Y, Risi S, Michel D, Knecht H, Perrelet R, Kraenzlin M, Zach GA, Lippuner K. (2004). Prevention of bone loss in paraplegics over 2 years with alendronate. Journal of Bone and Mineral Research : the Official Journal of the American Society for Bone and Mineral Research.
366 Zheng S, Wu Y, Zhang Z, Yang X, Hui Y, Zhang Y, Chen S, Deng W, Liu H, Ekangaki A, Stocks J, Harper K, Liu J. (2003). Effects of raloxifene hydrochloride on bone mineral density, bone metabolism and serum lipids in postmenopausal women: a randomized clinical trial in Beijing. Chin Med J (Engl).
367 Zheng SR, Wu YY, Zhang ZL, Yang X, Hui Y, Zhang Y, Chen SL, Den WH, Liu H, Ekangaki A, Stocks J, Harper K, Liu JL. (2003). [A randomised clinical trial to study the effects of raloxifene hydrochloride on bone mineral density, biochemical markers of bone metabolism and serum lipids in postmenopausal women]. Zhonghua Fu Chan Ke Za Zhi.

## REJECTED: No drug of interest

1 Adachi JD, Ioannidis G. (1999). Calcium and vitamin D therapy in corticosteroid-induced bone loss: what is the evidence?. Calcif Tissue Int.
2 Adami S, Braga V, Guidi G, Gatti D, Gerardi D, Fracassi E. (2000). Chronic intravenous aminobisphosphonate therapy increases high-density lipoprotein cholesterol and decreases low-density lipoprotein cholesterol. Journal of Bone and Mineral Research : the Official Journal of the American Society for Bone and Mineral Research.
3 Alexandersen P, Riis BJ, Stakkestad JA, Delmas PD, Christiansen C. (2001). Efficacy of levormeloxifene in the prevention of postmenopausal bone loss and on the lipid profile compared to low dose hormone replacement therapy. The Journal of Clinical Endocrinology and Metabolism.
4 Aloia JF, Cohn SH, Ostuni JA, Cane R, Ellis K. (1978). Prevention of involutional bone loss by exercise. Annals of Internal Medicine.
5 Amin S, LaValley MP, Simms RW, Felson DT. (1999). The role of vitamin D in corticosteroid-induced osteoporosis: a meta-analytic approach. Arthritis Rheum.
6 Barlow D. (2003). Strontium and osteoporosis. J Br Menopause Soc.
7 Bemben DA, Fetters NL, Bemben MG, Nabavi N, Koh ET. (2000). Musculoskeletal responses to high- and low-intensity resistance training in early postmenopausal women. Medicine and Science in Sports and Exercise.
8 Ben-Sasson SA, Finestone A, Moskowitz M, Maron R, Weinner M, Leichter I, Margulies J, Stein P, Popovtzer M, Rubinger D, et al. (1994). Extended duration of vertical position might impair bone metabolism. European Journal of Clinical Investigation.
9 Beresford SA, Johnson KC, Ritenbaugh C, Lasser NL, Snetselaar LG, Black HR, Anderson GL, Assaf AR, Bassford T, Bowen D, Brunner RL, Brzyski RG, Caan B, Chlebowski RT, Gass M, Harrigan RC, Hays J, Heber D, Heiss G, Hendrix SL, Howard BV, Hsia J, Hubbell FA, Jackson RD, Kotchen JM, Kuller LH, LaCroix AZ, Lane DS, Langer RD, Lewis CE, Manson JE, Margolis KL, Mossavar-Rahmani Y, Ockene JK, Parker LM, Perri MG, Phillips L, Prentice RL, Robbins J, Rossouw JE, Sarto GE, Stefanick ML, Van Horn L, Vitolins MZ, Wactawski-Wende J, Wallace RB, Whitlock E. (2006). Low-fat dietary pattern and risk of colorectal cancer: the Women's Health Initiative Randomized Controlled Dietary Modification Trial. JAMA.
10 Black DM, Cummings SR, Genant HK, Nevitt MC, Palermo L, Browner W. (1992). Axial and appendicular bone density predict fractures in older women. J Bone Miner Res.
11 Bostick RM, Potter JD, Sellers TA, McKenzie DR, Kushi LH, Folsom AR. (1993). Relation of calcium, vitamin D, and dairy food intake to incidence of colon cancer among older women. The Iowa Women's Health Study. Am J Epidemiol.
12 Bradney M, Pearce G, Naughton G, Sullivan C, Bass S, Beck T, Carlson J, Seeman E. (1998). Moderate exercise during growth in prepubertal boys: changes in bone mass, size, volumetric density, and bone strength: a controlled prospective study. J Bone Miner Res.
13 Braga V, Gatti D, Colapietro F, Battaglia E, Righetti D, Prizzi R, Rossini M, Adami S. (2003). Intravenous intermittent neridronate in the treatment of postmenopausal osteoporosis. Bone.
14 Braith RW, Mills RM, Welsch MA, Keller JW, Pollock ML. (1996). Resistance exercise training restores bone mineral density in heart transplant recipients. Journal of the American College of Cardiology.
15 Caraceni MP, Molteni N, Bardella MT, Ortolani S, Nogara A, Bianchi PA. (1988). Bone and mineral metabolism in adult celiac disease. The American Journal of Gastroenterology.
16 Chappard D, Minaire P, Privat C, Berard E, Mendoza-Sarmiento J, Tournebise H, Basle MF, Audran M, Rebel A, Picot C. (1995). Effects of tiludronate on bone loss in paraplegic patients. Journal of Bone and Mineral Research : the Official Journal of the American Society for Bone and Mineral Research.
17 Chevalley T, Rizzoli R, Nydegger V, Slosman D, Rapin CH, Michel JP, Vasey H, Bonjour JP. (1994). Effects of calcium supplements on femoral bone mineral density and vertebral fracture rate in vitamin-D-replete elderly patients. Osteoporos Int.
18 Chow RK, Harrison JE, Sturtridge W, et al. (1987). The effect of exercise on bone mass of osteoporotic patients on fluoride treatment. Clinical & Investigative Medicine.
19 Clark OH. (2003). How should patients with primary hyperparathyroidism be treated?. J Clin Endocrinol Metab.
20 Clowes JA, Peel NF, Eastell R. (2004). The impact of monitoring on adherence and persistence with antiresorptive treatment for postmenopausal osteoporosis: a randomized controlled trial. The Journal of Clinical Endocrinology and Metabolism.
21 Cooper C, Campion G, Melton LJ. (1992). Hip fractures in the elderly: a world-wide projection. Osteoporos Int.
22 Cummings S. (2004). Issues in designing and testing a “cure” for osteoporosis. J Musculoskelet Neuronal Interact.
23 Cummings SR, Browner WS, Bauer D, Stone K, Ensrud K, Jamal S, Ettinger B. (1998). Endogenous hormones and the risk of hip and vertebral fractures among older women. Study of Osteoporotic Fractures Research Group. N Engl J Med.
24 Cummings SR, Nevitt MC, Browner WS, Stone K, Fox KM, Ensrud KE, Cauley J, Black D, Vogt TM. (1995). Risk factors for hip fracture in white women. Study of Osteoporotic Fractures Research Group. N Engl J Med.
25 D'Haese PC, Santacruz F, De Broe ME. (2004). Postmenopausal osteoporosis and strontium ranelate. N Engl J Med.
26 Dambacher MA, Ittner J, Ruegsegger P. (1986). Long-term fluoride therapy of postmenopausal osteoporosis. Bone.
27 Dambacher, M. A.; Ittner, J., and Ruegsegger, P. Long-term fluoride therapy of postmenopausal osteoporosis. Bone. 2986; 7(199–205). Rec #: 3114
28 Danz AM, Zittermann A, Schiedermaier U, Klein K, Hotzel D, Schonau E. (1998). The effect of a specific strength-development exercise on bone mineral density in perimenopausal and postmenopausal women. Journal of Women's Health / the Official Publication of the Society for the Advancement of Women's Health Research.
29 Dawson-Hughes B, Harris SS, Krall EA, Dallal GE. (1997). Effect of calcium and vitamin D supplementation on bone density in men and women 65 years of age or older. N Engl J Med.
30 Dawson-Hughes B, Harris SS, Krall EA, Dallal GE, Falconer G, Green CL. (1995). Rates of bone loss in postmenopausal women randomly assigned to one of two dosages of vitamin D. Am J Clin Nutr.
31 de Jong N, Chin A, Paw MJ, de Groot LC, Hiddink GJ, van Staveren WA. (2000). Dietary supplements and physical exercise affecting bone and body composition in frail elderly persons. American Journal of Public Health.
32 Dechant KL, Goa KL. (1994). Calcitriol. A review of its use in the treatment of postmenopausal osteoporosis and its potential in corticosteroid-induced osteoporosis. Drugs Aging.
33 Delmas PD. (2005). Clinical effects of strontium ranelate in women with postmenopausal osteoporosis. Osteoporos Int.
34 Delmas PD, Eastell R, Garnero P, Seibel MJ, Stepan J. (2000). The use of biochemical markers of bone turnover in osteoporosis. Committee of Scientific Advisors of the International Osteoporosis Foundation. Osteoporos Int.
35 Di Loreto C, Ranchelli A, Lucidi P, Murdolo G, Parlanti N, De Cicco A, Tsarpela O, Annino G, Bosco C, Santeusanio F, Bolli GB, De Feo P. (2004). Effects of whole-body vibration exercise on the endocrine system of healthy men. J Endocrinol Invest.
36 Dibba, B.; Prentice, A.; Laskey, M. A.; Stirling, D. M., and Cole, T. J. An investigation of ethnic differences in bone mineral, hip axis length, calcium metabolism and bone turnover between West African and Caucasian adults living in the United Kingdom. Ann Hum Biol. 1999 May–1999 Jun 30; 26(3):229–42. Rec #: 2655
37 Dissemination, Centre for Reviews and. Aerobic exercise and bone density at the hip in postmenopausal women: a meta-analysis (Structured abstract). Database of Abstracts of Reviews of Effectiveness. 2005(3). Rec #: 1357
38 ---. Aerobic exercise and lumbar spine bone mineral density in postmenopausal women: a meta-analysis (Structured abstract). Database of Abstracts of Reviews of Effectiveness. 2005(3). Rec #: 1354
39 ---. The effect of exercise training programs on bone mass: a meta-analysis of published controlled trials in pre- and postmenopausal women (Structured abstract). Database of Abstracts of Reviews of Effectiveness. 2005(3). Rec #: 1349
40 ---. Exercise and bone mineral density in men: a meta-analysis (Structured abstract). Database of Abstracts of Reviews of Effectiveness. 2005(3). Rec #: 1338
41 ---. First- and second-year effects in trials of calcium supplementation on the loss of bone density in postmenopausal women (Structured abstract). Database of Abstracts of Reviews of Effectiveness. 2005(3). Rec #: 1325
42 ---. Meta-analysis of the effectiveness of physical activity for the prevention of bone loss in postmenopausal women (Structured abstract). Database of Abstracts of Reviews of Effectiveness. 2005(3). Rec #: 1317
43 ---. Resistance training and bone mineral density in women: a meta-analysis of controlled trials (Structured abstract). Database of Abstracts of Reviews of Effectiveness. 2005(3). Rec #: 1304
44 Donaldson LJ, Cook A, Thomson RG. (1990). Incidence of fractures in a geographically defined population. J Epidemiol Community Health.
45 Drinka, P. J. The importance of parathyroid hormone and vitamin D status in the treatment of osteoporosis and renal insufficiency. J Am Med Dir Assoc. 2006 Mar; 7(3 Suppl):S5–9, 4. Rec #: 3382
46 Eastell R, Hannon R. (2005). Long-term effects of aromatase inhibitors on bone. J Steroid Biochem Mol Biol.
47 Elomaa I, Risteli L. Laakso M. Lahtinen R. Virkkunen P. Risteli J. Monitoring the action of clodronate with type I collagen metabolites in multiple myeloma. European Journal of Cancer (Oxford, England. 1996; 1990) 32A(7):1166–70. Rec #: 1456
48 Farrerons J, Rodriguez de la Serna A, Guanabens N, Armadans L, Lopez-Navidad A, Yoldi B, Renau A, Vaque J. (1997). Sodium fluoride treatment is a major protector against vertebral and nonvertebral fractures when compared with other common treatments of osteoporosis: a longitudinal, observational study. Calcif Tissue Int.
49 Filipponi P, Cristallini S, Rizzello E, Policani G, Fedeli L, Gregorio F, Boldrini S, Troiani S, Massoni C. (1996). Cyclical intravenous clodronate in postmenopausal osteoporosis: results of a long-term clinical trial. Bone.
50 Fogelman I, Blake GM. (2005). Strontium ranelate for the treatment of osteoporosis. BMJ.
51 Friedlander AL, Genant HK, Sadowsky S, Byl NN, Gluer CC. (1995). A two-year program of aerobics and weight training enhances bone mineral density of young women. Journal of Bone and Mineral Research : the Official Journal of the American Society for Bone and Mineral Research.
52 Gail MH, Brinton LA, Byar DP, Corle DK, Green SB, Schairer C, Mulvihill JJ. (1989). Projecting individualized probabilities of developing breast cancer for white females who are being examined annually. J Natl Cancer Inst.
53 Gallagher JC, Goldgar D. (1990). Treatment of postmenopausal osteoporosis with high doses of synthetic calcitriol. A randomized controlled study. Ann Intern Med.
54 Gardner MJ, Brophy RH, Demetrakopoulos D, Koob J, Hong R, Rana A, Lin JT, Lane JM. (2005). Interventions to improve osteoporosis treatment following hip fracture. A prospective, randomized trial. The Journal of Bone and Joint Surgery American Volume.
55 Gaus W, WEstendorf J, Diebow R, Kieser M. (2005). Identification of adverse drug reactions by evaluation of a prescription database, demonstrated for “risk of bleeding”. Methods Inf Med.
56 Genant HK, Grampp S, Gluer CC, Faulkner KG, Jergas M, Engelke K, Hagiwara S, Van Kuijk C. (1994). Universal standardization for dual x-ray absorptiometry: patient and phantom cross-calibration results. J Bone Miner Res.
57 Ghiron LJ, Thompson JL, Holloway L, Hintz RL, Butterfield GE, Hoffman AR, Marcus R. (1995). Effects of recombinant insulin-like growth factor-I and growth hormone on bone turnover in elderly women. Journal of Bone and Mineral Research : the Official Journal of the American Society for Bone and Mineral Research.
58 Giannini S, D'Angelo A, Malvasi L, Castrignano R, Pati T, Tronca R, Liberto L, Nobile M, Crepaldi G. (1993). Effects of one-year cyclical treatment with clodronate on postmenopausal bone loss. Bone.
59 Giannini S, D'Angelo A, Sartori L, Passeri G, Dalle Carbonare L, Crepaldi G. (1996). Continuous and cyclical clodronate therapies and bone density in postmenopausal bone loss. Obstetrics and Gynecology.
60 Goldstein SR, Nanavati N. (2002). Adverse events that are associated with the selective estrogen receptor modulator levormeloxifene in an aborted phase III osteoporosis treatment study. American Journal of Obstetrics and Gynecology.
61 Goss PE, Ingle JN, Martino S, Robert NJ, Muss HB, Piccart MJ, Castiglione M, Tu D, Shepherd LE, Pritchard KI, Livingston RB, Davidson NE, Norton L, Perez EA, Abrams JS, Therasse P, Palmer MJ, Pater JL. (2003). A randomized trial of letrozole in postmenopausal women after five years of tamoxifen therapy for early-stage breast cancer. N Engl J Med.
62 Grecu EO, Weinshelbaum A, Simmons R. (1990). Effective therapy of glucocorticoid-induced osteoporosis with medroxyprogesterone acetate. Calcif Tissue Int.
63 Green JH, Booth C, Bunning R. (2002). Impact of supplementary high calcium milk with additional magnesium on parathyroid hormone and biochemical markers of bone turnover in postmenopausal women. Asia Pacific Journal of Clinical Nutrition.
64 Guglielmini C, Cavallini R, Mazzoni G, Ferrazzini S, Manfredini F, Valpondi V, Bagni B. (1995). Relationship between physical activity level and bone mineral density in two groups of female athletes. Q J Nucl Med.
65 Gutteridge DH, Robinson CJ, Joplin GF. (1968). Delayed strontium absorption in post-menopausal osteoporosis and osteomalacia. Clin Sci.
66 Haderslev KV, Tjellesen L, Sorensen HA, Staun M. (2002). Effect of cyclical intravenous clodronate therapy on bone mineral density and markers of bone turnover in patients receiving home parenteral nutrition. The American Journal of Clinical Nutrition.
67 Hamburg SM, Piers DA, van den Berg AP, Slooff MJ, Haagsma EB. (2000). Bone mineral density in the long term after liver transplantation. Osteoporos Int.
68 Hans D, Genton L, Drezner MK, Schott AM, Pacifici R, Avioli L, Slosman DO, Meunier PJ. (2002). Monitored impact loading of the hip: initial testing of a home-use device. Calcified Tissue International.
69 Hatori M, Hasegawa A, Adachi H, Shinozaki A, Hayashi R, Okano H, Mizunuma H, Murata K. (1993). The effects of walking at the anaerobic threshold level on vertebral bone loss in postmenopausal women. Calcified Tissue International.
70 Heaney, R. P. and Weaver, C. M. Calcium and vitamin D. Endocrinol Metab Clin North Am. 2003 Mar; 32(1):181–94, vii–viii. Rec #: 1021
71 Heinonen A, Oja P, Sievanen H, Pasanen M, Vuori I. (1998). Effect of two training regimens on bone mineral density in healthy perimenopausal women: a randomized controlled trial. Journal of Bone and Mineral Research : the Official Journal of the American Society for Bone and Mineral Research.
72 Homik, J.; Suarez-Almazor, M. E.; Shea, B.; Cranney, A.; Wells, G., and Tugwell, P. Calcium and vitamin D for corticosteroid-induced osteoporosis. Cochrane Database Syst Rev. 2000; (2):CD000952. Rec #: 2925
73 Homik, JJ. E. H.; Cranney, A.; Shea, B. J.; Suarez-Almazor, M. E.; Tugwell, P., and Wells, G. Calcium and vitamin D for corticosteroid-induced osteoporosis. Cochrane Database of Systematic Reviews. 2005(3). Rec #: 1159
74 Hosking, D. J.; Ross, P. D.; Thompson, D. E.; Wasnich, R. D.; McClung, M.; Bjarnason, N. H.; Ravn, P.; Cizza, G.; Daley, M., and Yates, A. J. Evidence that increased calcium intake does not prevent early postmenopausal bone loss. Clin Ther. 1998 Sep–1998 Oct 31; 20(5):933–44. Rec #: 2498
75 Howard BV, Van Horn L, Hsia J, Manson JE, Stefanick ML, Wassertheil-Smoller S, Kuller LH, LaCroix AZ, Langer RD, Lasser NL, Lewis CE, Limacher MC, Margolis KL, Mysiw WJ, Ockene JK, Parker LM, Perri MG, Phillips L, Prentice RL, Robbins J, Rossouw JE, Sarto GE, Schatz IJ, Snetselaar LG, Stevens VJ, Tinker LF, Trevisan M, Vitolins MZ, Anderson GL, Assaf AR, Bassford T, Beresford SA, Black HR, Brunner RL, Brzyski RG, Caan B, Chlebowski RT, Gass M, Granek I, Greenland P, Hays J, Heber D, Heiss G, Hendrix SL, Hubbell FA, Johnson KC, Kotchen JM. (2006). Low-fat dietary pattern and risk of cardiovascular disease: the Women's Health Initiative Randomized Controlled Dietary Modification Trial. JAMA.
76 Humphries B, Newton RU, Bronks R, Marshall S, McBride J, Triplett-McBride T, Hakkinen K, Kraemer WJ, Humphries N. (2000). Effect of exercise intensity on bone density, strength, and calcium turnover in older women. Medicine and Science in Sports and Exercise.
77 Hung CJ, Lee PC, Song CM, Chang YT, Tsai MT, Dai YS, Chen EJ, Lei HY, Lee PH, Lee CJ. (1996). Clinical implication of hormone treatment in postmenopausal kidney transplants. Transplant Proc.
78 Huuskonen J, Vaisanen SB, Kroger H, Jurvelin JS, Penttila I, Alhava E, Rauramaa R. (2002). Relation of sex hormones to bone mineral density in middle-aged men during a 4 year exercise intervention trial. Bone.
79 Huuskonen J, Vaisanen SB, Kroger H, Jurvelin JS, Alhava E, Rauramaa R. (2001). Regular physical exercise and bone mineral density: a four-year controlled randomized trial in middle-aged men. The DNASCO study. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
80 Ippoliti G, Pellegrini C, Campana C, Rinaldi M, D'Armini A, Goggi C, Aiello M, Vigano M. (2003). Clodronate treatment of established bone loss in cardiac recipients: a randomized study. Transplantation.
81 Ismail AA, Cockerill W, Cooper C, Finn JD, Abendroth K, Parisi G, Banzer D, Benevolenskaya LI, Bhalla AK, Armas JB, Cannata JB, Delmas PD, Dequeker J, Dilsen G, Eastell R, Ershova O, Falch JA, Felsch B, Havelka S, Hoszowski K, Jajic I, Kragl U, Johnell O, Lopez Vaz A, Lorenc R, Lyritis G, Marchand F, Masaryk P, Matthis C, Miazgowski T, Pols HA, Poor G, Rapado A, Raspe HH, Reid DM, Reisinger W, Janott J, Scheidt-Nave C, Stepan J, Todd C, Weber K, Woolf AD, Ambrecht G, Gowin W, Felsenberg D, Lunt M, Kanis JA, Reeve J, Silman AJ, O'Neill TW. (2001). Prevalent vertebral deformity predicts incident hip though not distal forearm fracture: results from the European Prospective Osteoporosis Study. Osteoporos Int.
82 Iwamoto J, Takeda T, Ichimura S. (2001). Effect of exercise training and detraining on bone mineral density in postmenopausal women with osteoporosis. Journal of Orthopaedic Science : Official Journal of the Japanese Orthopaedic Association.
83 Iwamoto J, Takeda T, Otani T, Yabe Y. (1998). Effect of increased physical activity on bone mineral density in postmenopausal osteoporotic women. The Keio Journal of Medicine.
84 Jadad AR, Moore RA, Carroll D, Jenkinson C, Reynolds DJ, Gavaghan DJ, McQuay HJ. (1996). Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials.
85 Jessup JV, Horne C, Vishen RK, Wheeler D. (2003). Effects of exercise on bone density, balance, and self-efficacy in older women. Biological Research for Nursing.
86 Johansen, A.; Evans, R. J.; Stone, M. D.; Richmond, P. W.; Lo, S. V., and Woodhouse, K. W. Fracture incidence in England and Wales: a study based on the population of Cardiff. Injury. 1997 Nov–1997 Dec 31; 28(9–10):655–60. Rec #: 2955
87 Jones G, Nguyen T, Sambrook PN, Kelly PJ, Gilbert C, Eisman JA. (1994). Symptomatic fracture incidence in elderly men and women: the Dubbo Osteoporosis Epidemiology Study (DOES). Osteoporos Int.
88 Kearney J, Giovannucci E, Rimm EB, Ascherio A, Stampfer MJ, Colditz GA, Wing A, Kampman E, Willett WC. (1996). Calcium, vitamin D, and dairy foods and the occurrence of colon cancer in men. Am J Epidemiol.
89 Keles, I.; Aydin, G.; Orkun, S.; Basar, M. M., and Batislam, E. Two clinical problems in elderly men: osteoporosis and erectile dysfunction. Arch Androl. 2005 May–2005 Jun 30; 51(3):177–84. Rec #: 2863
90 Kemmler W, Engelke K, Weineck J, Hensen J, Kalender WA. (2003). The Erlangen Fitness Osteoporosis Prevention Study: a controlled exercise trial in early postmenopausal women with low bone density-first-year results. Archives of Physical Medicine and Rehabilitation.
91 Kerr D, Ackland T, Maslen B, Morton A, Prince R. (2001). Resistance training over 2 years increases bone mass in calcium-replete postmenopausal women. Journal of Bone and Mineral Research : the Official Journal of the American Society for Bone and Mineral Research.
92 Klotzbuecher CM, Ross PD, Landsman PB, Abbott TA, Berger M. (2000). Patients with prior fractures have an increased risk of future fractures: a summary of the literature and statistical synthesis. J Bone Miner Res.
93 Kohrt WM, Ehsani AA, Birge SJ. (1997). Effects of exercise involving predominantly either joint-reaction or ground-reaction forces on bone mineral density in older women. Journal of Bone and Mineral Research : the Official Journal of the American Society for Bone and Mineral Research.
94 Kotowicz MA, Melton LJ, Cooper C, Atkinson EJ, O'Fallon WM, Riggs BL. (1994). Risk of hip fracture in women with vertebral fracture. J Bone Miner Res.
95 Kraemer WJ, Adams K, Cafarelli E, Dudley GA, Dooly C, Feigenbaum MS, Fleck SJ, Franklin B, Fry AC, Hoffman JR, Newton RU, Potteiger J, Stone MH, Ratamess NA, Triplett-McBride T. (2002). American College of Sports Medicine position stand. Progression models in resistance training for healthy adults. Med Sci Sports Exerc.
96 Landman JO, Hamdy NA, Pauwels EK, Papapoulos SE. (1995). Skeletal metabolism in patients with osteoporosis after discontinuation of long-term treatment with oral pamidronate. J Clin Endocrinol Metab.
97 Lau EM, Woo J, Leung PC, Swaminathan R, Leung D. (1992). The effects of calcium supplementation and exercise on bone density in elderly Chinese women. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
98 Lauritzen JB, Lund B. (1993). Risk of hip fracture after osteoporosis fractures. 451 women with fracture of lumbar spine, olecranon, knee or ankle. Acta Orthop Scand.
99 Lindsay R, Silverman SL, Cooper C, Hanley DA, Barton I, Broy SB, Licata A, Benhamou L, Geusens P, Flowers K, Stracke H, Seeman E. (2001). Risk of new vertebral fracture in the year following a fracture. JAMA.
100 Link TM, Guglielmi G, van Kuijk C, Adams JE. (2005). Radiologic assessment of osteoporotic vertebral fractures: diagnostic and prognostic implications. Eur Radiol.
101 Lips P, Duong T, Oleksik A, Black D, Cummings S, Cox D, Nickelsen T. (2001). A global study of vitamin D status and parathyroid function in postmenopausal women with osteoporosis: baseline data from the multiple outcomes of raloxifene evaluation clinical trial. J Clin Endocrinol Metab.
102 Lohman T, Going S, Pamenter R, Hall M, Boyden T, Houtkooper L, Ritenbaugh C, Bare L, Hill A, Aickin M. (1995). Effects of resistance training on regional and total bone mineral density in premenopausal women: a randomized prospective study. Journal of Bone and Mineral Research : the Official Journal of the American Society for Bone and Mineral Research.
103 Mackerras D, Lumley T. (1997). First- and second-year effects in trials of calcium supplementation on the loss of bone density in postmenopausal women. Bone.
104 Magno C, Anastasi G, Morabito N, Gaudio A, Maisano D, Franchina F, Gali A, Frisina N, Melloni D. (2005). Preventing bone loss during androgen deprivation therapy for prostate cancer: early experience with neridronate. Eur Urol.
105 Maimoun L, Mariano-Goulart D, Couret I, Manetta J, Peruchon E, Micallef JP, Verdier R, Rossi M, Leroux JL. (2004). Effects of physical activities that induce moderate external loading on bone metabolism in male athletes. Journal of Sports Sciences.
106 Martins SL, Curtis KM, Glasier AF. (2006). Combined hormonal contraception and bone health: a systematic review. Contraception.
107 McCloskey E, Selby P, Davies M, Robinson J, Francis RM, Adams J, Kayan K, Beneton M, Jalava T, Pylkkanen L, Kenraali J, Aropuu S, Kanis JA. (2004). Clodronate reduces vertebral fracture risk in women with postmenopausal or secondary osteoporosis: results of a double-blind, placebo-controlled 3-year study. Journal of Bone and Mineral Research : the Official Journal of the American Society for Bone and Mineral Research.
108 Melton LJ, Atkinson EJ, Cooper C, O'Fallon WM, Riggs BL. (1999). Vertebral fractures predict subsequent fractures. Osteoporos Int.
109 Melton LJ, Chrischilles EA, Cooper C, Lane AW, Riggs BL. (1992). Perspective. How many women have osteoporosis?. J Bone Miner Res.
110 Meunier, P. J. and Reginster, J. Y. (Department of Rheumatology and Bone Diseases, Pavillon F, Hopital Edouard Herriot, 69437, Lyon Cedex 3, France.). Design and methodology of the phase 3 trials for the clinical development of strontium ranelate in the treatment of women with postmenopausal osteoporosis. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA. Vol.14 Suppl 3, Pp.S66–76, 2003. 2003. Rec #: 2026
111 Meunier PJ, Roux C, Seeman E, Ortolani S, Badurski JE, Spector TD, Cannata J, Balogh A, Lemmel EM, Pors-Nielsen S, Rizzoli R, Genant HK, Reginster JY. (2004). The effects of strontium ranelate on the risk of vertebral fracture in women with postmenopausal osteoporosis. N Engl J Med.
112 Meunier PJ, Slosman DO, Delmas PD, Sebert JL, Brandi ML, Albanese C, Lorenc R, Pors-Nielsen S, De Vernejoul MC, Roces A, Reginster JY. (2002). Strontium ranelate: dose-dependent effects in established postmenopausal vertebral osteoporosis—a 2-year randomized placebo controlled trial. J Clin Endocrinol Metab.
113 Minaire, P. ; Depassio, J.; Berard, E.; Meunier, P. J.; Edouard, C.; Pilonchery, G., and Goedert, G. Effects of clodronate on immobilization bone loss. 1987. Rec #: 1743
114 Muratore M, Santacesaria G, Quarta E, Calcagnile F, Cosentino L, Muratore L. (2000). Prevention with clodronate of osteoporosis secondary to inhaled corticosteroid treatment in patients with chronic asthmatic bronchitis. Int J Clin Pharmacol Res.
115 Nakayama H, Yano T, Sagara Y, Ando K, Kasai Y, Taketani Y. (1997). Clinical usefulness of urinary CrossLaps as a sensitive marker of bone metabolism. Endocrine Journal.
116 Navarro MA, Formiga F, Blanco A, Bonnin MR, Nolla JM, Moga I. (1995). PDN-21 in premenopausal women with systemic lupus erythematosus treated with glucocorticoids. J Rheumatol.
117 Naveau B. (2004). Strontium: a new treatment for osteoporosis. Joint Bone Spine.
118 Nelson ME, Fisher EC, Dilmanian FA, Dallal GE, Evans WJ. (1991). A 1-y walking program and increased dietary calcium in postmenopausal women: effects on bone. The American Journal of Clinical Nutrition.
119 Nordborg E, Schaufelberger C, Andersson R, Bosaeus I, Bengtsson BA. (1997). The ineffectiveness of cyclical oral clodronate on bone mineral density in glucocorticoid-treated patients with giant-cell arteritis. Journal of Internal Medicine.
120 Oleksik A, Duong T, Popp-Snijders C, Pliester N, Asma G, Lips P. (2001). Effects of the selective oestrogen receptor modulator-raloxifene-on calcium and PTH secretory dynamics in women with osteoporosis. Clinical Endocrinology.
121 Ongphiphadhanakul B, Rajatanavin R, Chailurkit L, Piaseu N, Teerarungsikul K, Sirisriro R, Komindr S, Puavilai G. (1995). Serum testosterone and its relation to bone mineral density and body composition in normal males. Clin Endocrinol (Oxf).
122 Papapoulos SE, Landman JO, Bijvoet OL, Lowik CW, Valkema R, Pauwels EK, Vermeij P. (1992). The use of bisphosphonates in the treatment of osteoporosis. Bone.
123 Parodi PW. (2005). Dairy product consumption and the risk of breast cancer. J Am Coll Nutr.
124 Passeri M, Baroni MC, Pedrazzoni M, Pioli G, Barbagallo M, Costi D, Biondi M, Girasole G, Arlunno B, Palummeri E. (1991). Intermittent treatment with intravenous 4-amino-1-hydroxybutylidene-1,1-bisphosphonate (AHBuBP) in the therapy of postmenopausal osteoporosis. Bone and Mineral.
125 Pearce G, Tabensky DA, Delmas PD, Baker HW, Seeman E. (1998). Corticosteroid-induced bone loss in men. The Journal of Clinical Endocrinology and Metabolism.
126 Perez Cano R, Montoya MJ, Moruno R, Vazquez A, Galan F, Garrido M. (1989). Calcitonin reserve in healthy women and patients with postmenopausal osteoporosis. Calcif Tissue Int.
127 Piaseu N, Schepp K, Belza B. (2002). Causal analysis of exercise and calcium intake behaviors for osteoporosis prevention among young women in Thailand. Health Care for Women International.
128 Powles TJ, McCloskey E, Paterson AH, Ashley S, Tidy VA, Nevantaus A, Rosenqvist K, Kanis J. (1998). Oral clodronate and reduction in loss of bone mineral density in women with operable primary breast cancer. Journal of the National Cancer Institute.
129 Prentice RL, Caan B, Chlebowski RT, Patterson R, Kuller LH, Ockene JK, Margolis KL, Limacher MC, Manson JE, Parker LM, Paskett E, Phillips L, Robbins J, Rossouw JE, Sarto GE, Shikany JM, Stefanick ML, Thomson CA, Van Horn L, Vitolins MZ, Wactawski-Wende J, Wallace RB, Wassertheil-Smoller S, Whitlock E, Yano K, Adams-Campbell L, Anderson GL, Assaf AR, Beresford SA, Black HR, Brunner RL, Brzyski RG, Ford L, Gass M, Hays J, Heber D, Heiss G, Hendrix SL, Hsia J, Hubbell FA, Jackson RD, Johnson KC, Kotchen JM, LaCroix AZ, Lane DS, Langer RD, Lasser NL, Henderson MM. (2006). Low-fat dietary pattern and risk of invasive breast cancer: the Women's Health Initiative Randomized Controlled Dietary Modification Trial. JAMA.
130 Pruimboom L, van Dam B. (1997). [Treatment of osteoporosis by activation of endogenous physiological regenerative capacities]. Sportverletzung Sportschaden : Organ Der Gesellschaft Fur Orthopadisch-Traumatologische Sportmedizin.
131 Ramsey-Goldman R, Schilling EM, Dunlop D, Langman C, Greenland P, Thomas RJ, Chang RW. (2000). A pilot study on the effects of exercise in patients with systemic lupus erythematosus. Arthritis Care and Research : the Official Journal of the Arthritis Health Professions Association.
132 Recker RR, Hinders S, Davies KM, Heaney RP, Stegman MR, Lappe JM, Kimmel DB. (1996). Correcting calcium nutritional deficiency prevents spine fractures in elderly women. J Bone Miner Res.
133 Reginster JY. (2002). Strontium ranelate in osteoporosis. Curr Pharm Des.
134 Reginster, J. Y.; Christiansen, C.; Roux, C.; Fechtenbaum, J.; Rouillon, A., and Tou, K. P. (WHO Collaborating Center for Public Health Aspects of Osteoarticular Disorders, Department of Epidemiology and Public Health, University of Liege, Liege, Belgium. jyreginster@ulg.ac.be). Intermittent cyclic tiludronate in the treatment of osteoporosis. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA. 12(3):169–77, 2001. 2001. Rec #: 2032
135 Reginster JY, Deroisy R, Dougados M, Jupsin I, Colette J, Roux C. (2002). Prevention of early postmenopausal bone loss by strontium ranelate: the randomized, two-year, double-masked, dose-ranging, placebo-controlled PREVOS trial. Osteoporos Int.
136 Reginster JY, Lecart MP, Deroisy R, Sarlet N, Denis D, Ethgen D, Collette J, Franchimont P. (1989). Prevention of postmenopausal bone loss by tiludronate. Lancet.
137 Reginster, J. Y. and Meunier, P. J. (Bone and Cartilage Metabolism Unit, CHU Centre Ville, Quai Godefroid Kurth 45 (+9), 4020, Liege, Belgium. jyreginster@ulg.ac.be). Strontium ranelate phase 2 dose-ranging studies: PREVOS and STRATOS studies. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA. Vol.14 Suppl 3, Pp.S56–65, 2003. 2003. Rec #: 2027
138 Reginster JY, Seeman E, De Vernejoul MC, Adami S, Compston J, Phenekos C, Devogelaer JP, Curiel MD, Sawicki A, Goemaere S, Sorensen OH, Felsenberg D, Meunier PJ. (2005). Strontium ranelate reduces the risk of nonvertebral fractures in postmenopausal women with osteoporosis: Treatment of Peripheral Osteoporosis (TROPOS) study. J Clin Endocrinol Metab.
139 Remes T, Vaisanen SB, Mahonen A, Huuskonen J, Kroger H, Jurvelin JS, Penttila IM, Rauramaa R. (2004). The association of bone metabolism with bone mineral density, serum sex hormone concentrations, and regular exercise in middle-aged men. Bone.
140 Remes T, Vaisanen SB, Mahonen A, Huuskonen J, Kroger H, Jurvelin JS, Penttila IM, Rauramaa R. (2003). Aerobic exercise and bone mineral density in middle-aged finnish men: a controlled randomized trial with reference to androgen receptor, aromatase, and estrogen receptor alpha gene polymorphisms small star, filled. Bone.
141 Riggs BL, Seeman E, Hodgson SF, Taves DR, O'Fallon WM. (1982). Effect of the fluoride/calcium regimen on vertebral fracture occurrence in postmenopausal osteoporosis: comparison with conventional therapy. N Engl J Med.
142 Rizzoli R, Forni M, Schaad MA, Slosman DO, Sappino AP, Garcia J, Bonjour JP. (1996). Effects of oral clodronate on bone mineral density in patients with relapsing breast cancer. Bone.
143 Rong H, Berg U, Torring O, Sundberg CJ, Granberg B, Bucht E. (1997). Effect of acute endurance and strength exercise on circulating calcium-regulating hormones and bone markers in young healthy males. Scand J Med Sci Sports.
144 Ross PD, Davis JW, Epstein RS, Wasnich RD. (1994). Pain and disability associated with new vertebral fractures and other spinal conditions. J Clin Epidemiol.
145 ---. Pre-existing fractures and bone mass predict vertebral fracture incidence in women. Ann Intern Med. 1991 Jun 1; 114(11):919–23. Rec #: 2945
146 Rossini M, Braga V, Gatti D, Gerardi D, Zamberlan N, Adami S. (1999). Intramuscular clodronate therapy in postmenopausal osteoporosis. Bone.
147 Rozen P, Fireman Z, Fine N, Wax Y, Ron E. (1989). Oral calcium suppresses increased rectal epithelial proliferation of persons at risk of colorectal cancer. Gut.
148 Rudman D, Drinka PJ, Wilson CR, Mattson DE, Scherman F, Cuisinier MC, Schultz S. (1994). Relations of endogenous anabolic hormones and physical activity to bone mineral density and lean body mass in elderly men. Clin Endocrinol (Oxf).
149 Rutanen, E. M.; Heikkinen, J.; Halonen, K.; Komi, J.; Lammintausta, R., and Ylikorkala, O. Effects of ospemifene, a novel SERM, on hormones, genital tract, climacteric symptoms, and quality of life in postmenopausal women: a double-blind, randomized trial. Menopause. 2003 Sep–2003 Oct 31; 10(5):433–9. Rec #: 1210
150 Ryan AS, Treuth MS, Rubin MA, Miller JP, Nicklas BJ, Landis DM, Pratley RE, Libanati CR, Gundberg CM, Hurley BF. (1994). Effects of strength training on bone mineral density: hormonal and bone turnover relationships. J Appl Physiol.
151 Saarto T, Vehmanen L, Elomaa I, Valimaki M, Makela P, Blomqvist C. (2001). The effect of clodronate and antioestrogens on bone loss associated with oestrogen withdrawal in postmenopausal women with breast cancer. British Journal of Cancer.
152 Sambrook P. (1992). Calcitriol and postmenopausal osteoporosis. Med J Aust.
153 Schneider P, Berger P, Kruse K, Borner W. (1991). Effect of calcitonin deficiency on bone density and bone turnover in totally thyroidectomized patients. J Endocrinol Invest.
154 See Tai, S. ; Parsons, T.; Rutherford, O., and Iliffe, S. Physical activity for preventing and treating osteoporosis in men. Cochrane Database of Systematic Reviews. 2005(3). Rec #: 1250
155 Seeley DG, Browner WS, Nevitt MC, Genant HK, Scott JC, Cummings SR. (1991). Which fractures are associated with low appendicular bone mass in elderly women? The Study of Osteoporotic Fractures Research Group. Ann Intern Med.
156 Seguin R, Nelson ME. (2003). The benefits of strength training for older adults. Am J Prev Med.
157 Sellers TA, Bazyk AE, Bostick RM, Kushi LH, Olson JE, Anderson KE, Lazovich D, Folsom AR. (1998). Diet and risk of colon cancer in a large prospective study of older women: an analysis stratified on family history (Iowa, United States). Cancer Causes Control.
158 Shibata Y, Ohsawa I, Watanabe T, Miura T, Sato Y. (2003). Effects of physical training on bone mineral density and bone metabolism. Journal of Physiological Anthropology and Applied Human Science.
159 Shimegi S, Yanagita M, Okano H, Yamada M, Fukui H, Fukumura Y, Ibuki Y, Kojima I. (1994). Physical exercise increases bone mineral density in postmenopausal women. Endocr J.
160 Silverberg SJ. (2002). Non-classical target organs in primary hyperparathyroidism. J Bone Miner Res.
161 Silverberg SJ, Shane E, Jacobs TP, Siris E, Bilezikian JP. (1999). A 10-year prospective study of primary hyperparathyroidism with or without parathyroid surgery. N Engl J Med.
162 Silverman SL, Delmas PD, Kulkarni PM, Stock JL, Wong M, Plouffe L. (2004). Comparison of fracture, cardiovascular event, and breast cancer rates at 3 years in postmenopausal women with osteoporosis. J Am Geriatr Soc.
163 Sinaki M, Itoi E, Wahner HW, Wollan P, Gelzcer R, Mullan BP, Collins DA, Hodgson SF. (2002). Stronger back muscles reduce the incidence of vertebral fractures: a prospective 10 year follow-up of postmenopausal women. Bone.
164 Sinaki M, Canvin JC, Phillips BE, Clarke BL. (2004). Site specificity of regular health club exercise on muscle strength, fitness, and bone density in women aged 29 to 45 years. Mayo Clinic Proceedings.
165 Sjoberg HE, Torring O, Granberg B, Ehrnsten U, Bucht E. (1989). Postmenopausal osteoporosis: response of immunoextracted calcitonin to a calcium clamp. Bone.
166 Skrumsager BK, Kiehr B, Pedersen PC, Gerrits M, Watson N, Bjarnason K. (2002). Levormeloxifene: safety, pharmacodynamics and pharmacokinetics in healthy postmenopausal women following single and multiple doses of a new selective oestrogen receptor modulator. British Journal of Clinical Pharmacology.
167 Smith EL, Reddan W, Smith PE. (1981). Physical activity and calcium modalities for bone mineral increase in aged woman. Medicine Science Sports Exercise.
168 Steinberg KK, Freni-Titulaer LW, DePuey EG, Miller DT, Sgoutas DS, Coralli CH, Phillips DL, Rogers TN, Clark RV. (1989). Sex steroids and bone density in premenopausal and perimenopausal women. J Clin Endocrinol Metab.
169 Stemmermann GN, Nomura A, Chyou PH. (1990). The influence of dairy and nondairy calcium on subsite large-bowel cancer risk. Dis Colon Rectum.
170 Stempfle HU, Werner C, Echtler S, Wehr U, Rambeck WA, Siebert U, Uberfuhr P, Angermann CE, Theisen K, Gartner R. (1999). Prevention of osteoporosis after cardiac transplantation: a prospective, longitudinal, randomized, double-blind trial with calcitriol. Transplantation.
171 Strippoli GF, Palmer S, Tong A, Elder G, Messa P, Craig JC. (2006). Meta-analysis of biochemical and patient-level effects of calcimimetic therapy. Am J Kidney Dis.
172 Talalaj M, Gradowska L, Marcinowska-Suchowierska E, Durlik M, Gaciong Z, Lao M. (1996). Efficiency of preventive treatment of glucocorticoid-induced osteoporosis with 25-hydroxyvitamin D3 and calcium in kidney transplant patients. Transplantation Proceedings.
173 Tattersfield AE, Town GI, Johnell O, Picado C, Aubier M, Braillon P, Karlstrom R. (2001). Bone mineral density in subjects with mild asthma randomised to treatment with inhaled corticosteroids or non-corticosteroid treatment for two years. Thorax.
174 Taur Y, Al-Tureihi F, Wolf-Klein G. (2004). Postmenopausal osteoporosis and strontium ranelate. N Engl J Med.
175 Tsai KS, Hsu SH, Yang RS, Cheng WC, Chieng PU. (1999). The effectiveness of cyclic and continuous oral clodronate therapy on bone density and markers in osteopenic postmenopausal women. Calcified Tissue International.
176 van Staa TP, Dennison EM, Leufkens HG, Cooper C. (2001). Epidemiology of fractures in England and Wales. Bone.
177 Van Staa TP, Leufkens HG, Abenhaim L, Zhang B, Cooper C. (2000). Use of oral corticosteroids and risk of fractures. J Bone Miner Res.
178 Verschueren SM, Roelants M, Delecluse C, Swinnen S, Vanderschueren D, Boonen S. (2004). Effect of 6-month whole body vibration training on hip density, muscle strength, and postural control in postmenopausal women: a randomized controlled pilot study. J Bone Miner Res.
179 Wasnich R. (1993). Bone mass measurement: prediction of risk. Am J Med.
180 White E, Shannon JS, Patterson RE. (1997). Relationship between vitamin and calcium supplement use and colon cancer. Cancer Epidemiol Biomarkers Prev.
181 Wickman S, Kajantie E, Dunkel L. (2003). Effects of suppression of estrogen action by the p450 aromatase inhibitor letrozole on bone mineral density and bone turnover in pubertal boys. J Clin Endocrinol Metab.
182 Wu AH, Paganini-Hill A, Ross RK, Henderson BE. (1987). Alcohol, physical activity and other risk factors for colorectal cancer: a prospective study. Br J Cancer.
183 Yoles I, Yogev Y, Frenkel Y, Nahum R, Hirsch M, Kaplan B. (2003). Tofupill/Femarelle (DT56a): a new phyto-selective estrogen receptor modulator-like substance for the treatment of postmenopausal bone loss. Menopause (New York, NY).
184 Yu-Yahiro JA, Michael RH, Dubin NH, Fox KM, Sachs M, Hawkes WG, Hebel JR, Zimmerman SI, Shapiro J, Magaziner J. (2001). Serum and urine markers of bone metabolism during the year after hip fracture. J Am Geriatr Soc.

## REJECTED: No condition of interest

1 Erratum: Raloxifene rduces risk of vertebral fractures in post-,enopausal women regardless of prior hormone therapy (Journal of Family Practice(October 2004)). Journal of Family Practice. 2005; 54(3):276. Rec #: 3468
2 Review: Bisphosphonates prevent or delay skeletal events in women with advanced breast cancer and bone metastases. ACP Journal Club. 2006; 144(2):39. Rec #: 3268
3 Adams D. (2005). Raloxifene for hormone replacement therapy (HRT). N Z Med J.
4 Agarwala S, Sule A, Pai BU, Joshi VR. (2001). Study of alendronate in avascular necrosis of bone. J Assoc Physicians India.
5 Al Sarakbi, W.; Salhab, M., and Mokbel, K. Dairy products and breast cancer risk: a review of the literature. Int J Fertil Womens Med. 2005 Nov–2005 Dec 31; 50(6):244–9. Rec #: 3493
6 Anderson RA, Wallace AM, Sattar N, Kumar N, Sundaram K. (2003). Evidence for tissue selectivity of the synthetic androgen 7 alpha-methyl-19-nortestosterone in hypogonadal men. J Clin Endocrinol Metab.
7 Barrett-Connor E, Mosca L, Collins P, Geiger MJ, Grady D, Kornitzer M, McNabb MA, Wenger NK. (2006). Effects of raloxifene on cardiovascular events and breast cancer in postmenopausal women. N Engl J Med.
8 Barrett-Connor E, Slone S, Greendale G, Kritz-Silverstein D, Espeland M, Johnson SR, Waclawiw M, Fineberg SE. (1997). The Postmenopausal Estrogen/Progestin Interventions Study: primary outcomes in adherent women. Maturitas.
9 Bauer DC, Garnero P, Hochberg MC, Santora A, Delmas P, Ewing SK, Black DM. (2006). Pretreatment levels of bone turnover and the antifracture efficacy of alendronate: the fracture intervention trial. J Bone Miner Res.
10 Baum M, Buzdar A, Cuzick J, Forbes J, Houghton J, Howell A, Sahmoud T. (2003). Anastrozole alone or in combination with tamoxifen versus tamoxifen alone for adjuvant treatment of postmenopausal women with early-stage breast cancer: results of the ATAC (Arimidex, Tamoxifen Alone or in Combination) trial efficacy and safety update analyses. Cancer.
11 Berenson JR, Lichtenstein A, Porter L, Dimopoulos MA, Bordoni R, George S, Lipton A, Keller A, Ballester O, Kovacs M, Blacklock H, Bell R, Simeone JF, Reitsma DJ, Heffernan M, Seaman J, Knight RD. (1998). Long-term pamidronate treatment of advanced multiple myeloma patients reduces skeletal events. Myeloma Aredia Study Group. Journal of Clinical Oncology : Official Journal of the American Society of Clinical Oncology.
12 Bickerstaff DR, Kanis JA. (1991). The use of nasal calcitonin in the treatment of post-traumatic algodystrophy. British Journal of Rheumatology.
13 Bloch Thomsen A, Silvestri S, Christiansen C, Bjarnason NH. (2003). Associated response in bone mineral density and atherogenic lipid profile during treatment with two different selective estrogen receptor modulators: Levormeloxifene and raloxifene. Climacteric.
14 Body JJ, Diel IJ, Lichinitzer M, Lazarev A, Pecherstorfer M, Bell R, Tripathy D, Bergstrom B. (2004). Oral ibandronate reduces the risk of skeletal complications in breast cancer patients with metastatic bone disease: results from two randomised, placebo-controlled phase III studies. Br J Cancer.
15 Bolognese, M.; McIntyre, D., and Fogelman, I. Risedronate is well-tolerated in patients with osteoporosis including those over 80 years of age. 2000; 11, (suppl 2): 440. Rec #: 3144
16 Braithwaite RS, Chlebowski RT, Lau J, George S, Hess R, Col NF. (2003). Meta-analysis of vascular and neoplastic events associated with tamoxifen. J Gen Intern Med.
17 Buclin T, Cosma Rochat M, Burckhardt P, Azria M, Attinger M. (2002). Bioavailability and biological efficacy of a new oral formulation of salmon calcitonin in healthy volunteers. Journal of Bone and Mineral Research : the Official Journal of the American Society for Bone and Mineral Research.
18 Buist DS, LaCroix AZ, Black DM, Harris F, Blank J, Ensrud K, Edgerton D, Rubin S, Fox KM. (2000). Inclusion of older women in randomized clinical trials: factors associated with taking study medication in the fracture intervention trial. J Am Geriatr Soc.
19 Byington RP, Furberg CD, Herrington DM, Herd JA, Hunninghake D, Lowery M, Riley W, Craven T, Chaput L, Ireland CC, Applegate WB. (2002). Effect of estrogen plus progestin on progression of carotid atherosclerosis in postmenopausal women with heart disease: HERS B-mode substudy. Arterioscler Thromb Vasc Biol.
20 Calle EE, Miracle-McMahill HL, Thun MJ, Heath CW. (1995). Estrogen replacement therapy and risk of fatal colon cancer in a prospective cohort of postmenopausal women. J Natl Cancer Inst.
21 Camisasca M, Crosignani A, Battezzati PM, Albisetti W, Grandinetti G, Pietrogrande L, Biffi A, Zuin M, Podda M. (1994). Parenteral calcitonin for metabolic bone disease associated with primary biliary cirrhosis. Hepatology (Baltimore, Md).
22 Canto-Costa MH, Kunii I, Hauache OM. (2006). Body fat and cholecalciferol supplementation in elderly homebound individuals. Braz J Med Biol Res.
23 Castelo-Branco C, Martinez de Osaba MJ, Pons F, Fortuny A. (1997). Gonadotropin-releasing hormone analog plus an oral contraceptive containing desogestrel in women with severe hirsutism: effects on hair, bone, and hormone profile after 1-year use. Metabolism.
24 Cauley, J.; Krueger, K.; Eckert, S.; Muchmore, D.; Taylor, Y., and Scott, T. Breast cancer risk in postmenopausal women with osteoporosis is reduced with raloxifene treatment: extension of the MORE trial data to a median follow-up of 52 months [abstract]. American Society of Clincial Oncology 36th Annual Meeting; New Orleans. Rec #: 1099
25 Ceresini, G.; Morganti, S.; Rebecchi, I.; Bertone, L.; Ceda, G. P.; Bacchi-Modena, A.; Sgarabotto, M.; Baldini, M.; Ablondi, F.; Valenti, G., and Braverman, L. E. A one-year follow-up on the effects of raloxifene on thyroid function in postmenopausal women. Menopause. 2004 Mar–2004 Apr 30; 11(2):176–9. Rec #: 2591
26 Chan JM, Pietinen P, Virtanen M, Malila N, Tangrea J, Albanes D, Virtamo J. (2000). Diet and prostate cancer risk in a cohort of smokers, with a specific focus on calcium and phosphorus (Finland). Cancer Causes Control.
27 Chang J, Powles TJ, Ashley SE, Gregory RK, Tidy VA, Treleaven JG, Singh R. (1996). The effect of tamoxifen and hormone replacement therapy on serum cholesterol, bone mineral density and coagulation factors in healthy postmenopausal women participating in a randomised, controlled tamoxifen prevention study. Ann Oncol.
28 Chen P, Lai JM, Deng JF, Lu SB, Ku H. (2000). Relative bioavailability of salmon calcitonin given intramuscularly. Zhonghua Yi Xue Za Zhi = Chinese Medical Journal; Free China Ed.
29 Chrischilles EA, Dasbach EJ, Rubenstein LM, Cook JR, Tabor HK, Black DM. (2001). The effect of alendronate on fracture-related healthcare utilization and costs: the fracture intervention trial. Osteoporos Int.
30 Christmas C, O'Connor KG, Harman SM, Tobin JD, Munzer T, Bellantoni MF, Clair CS, Pabst KM, Sorkin JD, Blackman MR. (2002). Growth hormone and sex steroid effects on bone metabolism and bone mineral density in healthy aged women and men. The Journals of Gerontology Series A, Biological Sciences and Medical Sciences.
31 Christodoulakos, G. E.; Lambrinoudaki, I. V.; Vourtsi, A. D.; Panoulis, K. P.; Kelekis, D. A., and Creatsas, G. C. Mammographic changes associated with raloxifene and tibolone therapy in postmenopausal women: a prospective study. Menopause. 2002 Mar–2002 Apr 30; 9(2):110–6. Rec #: 2599
32 Clemons MJ, Dranitsaris G, Ooi WS, Yogendran G, Sukovic T, Wong BY, Verma S, Pritchard KI, Trudeau M, Cole DE. (2006). Phase II trial evaluating the palliative benefit of second-line zoledronic acid in breast cancer patients with either a skeletal-related event or progressive bone metastases despite first-line bisphosphonate therapy. J Clin Oncol.
33 Coleman RE. (2000). Optimising treatment of bone metastases by Aredia(TM) and Zometa(TM). Breast Cancer.
34 Collaborative Group on Hormonal Factors in Breast Cancer. (1997). Breast cancer and hormone replacement therapy: collaborative reanalysis of data from 51 epidemiological studies of 52,705 women with breast cancer and 108,411 women without breast cancer. Lancet.
35 Cox DA, Sarkar S, Harper K, Barrett-Connor E. (2004). Effect of raloxifene on the incidence of elevated low density lipoprotein (LDL) and achievement of LDL target goals in postmenopausal women. Current Medical Research and Opinion.
36 Crandall CJ. (1999). Estrogen replacement therapy and colon cancer: a clinical review. J Womens Health Gend Based Med.
37 Cremers SC, Lodder MC, Den Hartigh J, Vermeij P, Van Pelt P, Lems WF, Papapoulos SE, Dijkmans BA. (2004). Short term whole body retention in relation to rate of bone resorption and cartilage degradation after intravenous bisphosphonate (pamidronate) in rheumatoid arthritis. The Journal of Rheumatology.
38 Cuzick J, Allen D, Baum M, Barrett J, Clark G, Kakkar V, Melissari E, Moniz C, Moore J, Parsons V, et al. (1992). Long term effects of tamoxifen. Biological effects of Tamoxifen Working Party. Eur J Cancer.
39 Cuzick J, Forbes J, Edwards R, Baum M, Cawthorn S, Coates A, Hamed A, Howell A, Powles T. (2002). First results from the International Breast Cancer Intervention Study (IBIS-I): a randomised prevention trial. Lancet.
40 De Leo V, la Marca A, Morgante G, Lanzetta D, Setacci C, Petraglia F. (2001). Randomized control study of the effects of raloxifene on serum lipids and homocysteine in older women. American Journal of Obstetrics and Gynecology.
41 de Valk-de Roo GW, Stehouwer CD, Meijer P, Mijatovic V, Kluft C, Kenemans P, Cohen F, Watts S, Netelenbos C. (1999). Both raloxifene and estrogen reduce major cardiovascular risk factors in healthy postmenopausal women: A 2-year, placebo-controlled study. Arterioscler Thromb Vasc Biol.
42 Dickler MN, Norton L. (2001). The MORE trial: multiple outcomes for raloxifene evaluation—breast cancer as a secondary end point: implications for prevention. Ann N Y Acad Sci.
43 Dissemination, C. f. R. a. Effect of bisphosphonates on periprosthetic bone mineral density after total joint arthroplasty: a meta-analysis (Provisional record). Database of Abstracts of Reviews of Effects. 2006; (2). Rec #: 3250
44 Ensrud KE, Thompson DE, Cauley JA, Nevitt MC, Kado DM, Hochberg MC, Santora AC, Black DM. (2000). Prevalent vertebral deformities predict mortality and hospitalization in older women with low bone mass. Fracture Intervention Trial Research Group. J Am Geriatr Soc.
45 Espeland MA, Bush TL, Mebane-Sims I, Stefanick ML, Johnson S, Sherwin R, Waclawiw M. (1995). Rationale, design, and conduct of the PEPI Trial. Postmenopausal Estrogen/Progestin Interventions. Control Clin Trials.
46 Evio S, Tarkkila L, Sorsa T, Furuholm J, Valimaki MJ, Ylikorkala O, Tiitinen A, Meurman JH. (2006). Effects of alendronate and hormone replacement therapy, alone and in combination, on saliva, periodontal conditions and gingival crevicular fluid matrix metalloproteinase-8 levels in women with osteoporosis. Oral Dis.
47 Fernandez E, La Vecchia C, Braga C, Talamini R, Negri E, Parazzini F, Franceschi S. (1998). Hormone replacement therapy and risk of colon and rectal cancer. Cancer Epidemiol Biomarkers Prev.
48 Fleisch H. (1991). Bisphosphonates: pharmacology and use in the treatment of tumour-induced hypercalcaemic and metastic bone disease. Drugs.
49 Fornander T, Rutqvist LE, Sjoberg HE, Blomqvist L, Mattsson A, Glas U. (1990). Long-term adjuvant tamoxifen in early breast cancer: effect on bone mineral density in postmenopausal women. J Clin Oncol.
50 Fraser WD, Ahmad AM, Vora JP. (2004). The physiology of the circadian rhythm of parathyroid hormone and its potential as a treatment for osteoporosis. Curr Opin Nephrol Hypertens.
51 Fugere P, Scheele WH, Shah A, Strack TR, Glant MD, Jolly E. (2000). Uterine effects of raloxifene in comparison with continuous-combined hormone replacement therapy in postmenopausal women. Am J Obstet Gynecol.
52 Fugh-Berman A, Epstein S. (1992). Should healthy women take tamoxifen?. The New England Journal of Medicine.
53 Furlong TJ, Seshadri MS, Wilkinson MR, Cornish CJ, Luttrell B, Posen S. (1986). Clinical experiences with human parathyroid hormone 1–34. Aust N Z J Med.
54 Gail MH, Costantino JP. (2001). Validating and improving models for projecting the absolute risk of breast cancer. J Natl Cancer Inst.
55 Gallagher, J. C.; Rapuri, P. B., and Smith, L. M. An Age Related Decrease in Creatinine Clearance is Associated with an Increase in Number of Falls in Untreated Women but not in Women Receiving Calcitriol Treatment. J Clin Endocrinol Metab. 2006 Oct 10. Rec #: 3543
56 Gaugris S, Heaney RP, Boonen S, Kurth H, Bentkover JD, Sen SS. (2005). Vitamin D inadequacy among post-menopausal women: a systematic review. QJM.
57 Genant HK, Siris E, Crans GG, Desaiah D, Krege JH. (2005). Reduction in vertebral fracture risk in teriparatide-treated postmenopausal women as assessed by spinal deformity index. Bone.
58 Genco, R. J. ; van Dyke, T.; Leung, A., and et al. Two-year gastrointestinal safety and tolerability of alendronate 70mg once weekly [abstract]. 2001; 16, (Suppl 1): S528 Abstract M404. Rec #: 2957
59 Glueck CJ, Phillips HG, Cameron D, Wang P. (2001). Estrogen replacement in a protein S deficient patient leads to diarrhea, hyperglucagonemia, and osteonecrosis. JOP.
60 Goldstein SR, Johnson S, Watts NB, Ciaccia AV, Elmerick D, Muram D. (2005). Incidence of urinary incontinence in postmenopausal women treated with raloxifene or estrogen. Menopause.
61 Goldstein SR, Scheele WH, Rajagopalan SK, Wilkie JL, Walsh BW, Parsons AK. (2000). A 12-month comparative study of raloxifene, estrogen, and placebo on the postmenopausal endometrium. Obstet Gynecol.
62 Gotfredsen A, Christiansen C, Palshof T. (1984). The effect of tamoxifen on bone mineral content in premenopausal women with breast cancer. Cancer.
63 Grady D, Applegate W, Bush T, Furberg C, Riggs B, Hulley SB. (1998). Heart and Estrogen/progestin Replacement Study (HERS): design, methods, and baseline characteristics. Control Clin Trials.
64 Grady D, Herrington D, Bittner V, Blumenthal R, Davidson M, Hlatky M, Hsia J, Hulley S, Herd A, Khan S, Newby LK, Waters D, Vittinghoff E, Wenger N. (2002). Cardiovascular disease outcomes during 6.8 years of hormone therapy: Heart and Estrogen/progestin Replacement Study follow-up (HERS II). JAMA.
65 Grady D, Wenger NK, Herrington D, Khan S, Furberg C, Hunninghake D, Vittinghoff E, Hulley S. (2000). Postmenopausal hormone therapy increases risk for venous thromboembolic disease. The Heart and Estrogen/progestin Replacement Study. Ann Intern Med.
66 Grady D, Yaffe K, Kristof M, Lin F, Richards C, Barrett-Connor E. (2002). Effect of postmenopausal hormone therapy on cognitive function: the Heart and Estrogen/progestin Replacement Study. Am J Med.
67 Graham DY, Malaty HM. (1999). Alendronate gastric ulcers. Alimentary Pharmacology & Therapeutics.
68 Grigoriev AI, Morukov BV, Oganov VS, Rakhmanov AS, Buravkova LB. (1992). Effect of exercise and bisphosphonate on mineral balance and bone density during 360 day antiorthostatic hypokinesia. J Bone Miner Res.
69 Grotz W, Rump JA, Niessen A, Schmidt-Gayk H, Schollmeyer P. (1998). Treatment of bone pain after kidney transplantation. Transplantation Proceedings.
70 Guanabens N, Pares A, Monegal A, Peris P, Pons F, Alvarez L, de Osaba MJ, Roca M, Torra M, Rodes J. (1997). Etidronate versus fluoride for treatment of osteopenia in primary biliary cirrhosis: preliminary results after 2 years. Gastroenterology.
71 Hartman TJ, Albert PS, Snyder K, Slattery ML, Caan B, Paskett E, Iber F, Kikendall JW, Marshall J, Shike M, Weissfeld J, Brewer B, Schatzkin A, Lanza E. (2005). The association of calcium and vitamin D with risk of colorectal adenomas. J Nutr.
72 Hasegawa J, Nagashima M, Yamamoto M, Nishijima T, Katsumata S, Yoshino S. (2003). Bone resorption and inflammatory inhibition efficacy of intermittent cyclical etidronate therapy in rheumatoid arthritis. The Journal of Rheumatology.
73 Henry JG, Mitnick M, Dann PR, Stewart AF. (1997). Parathyroid hormone-related protein-(1–36) is biologically active when administered subcutaneously to humans. J Clin Endocrinol Metab.
74 Herrington DM, Fong J, Sempos CT, Black DM, Schrott HG, Rautaharju P, Bachorik PS, Blumenthal R, Khan S, Wenger NK. (1998). Comparison of the Heart and Estrogen/Progestin Replacement Study (HERS) cohort with women with coronary disease from the National Health and Nutrition Examination Survey III (NHANES III). Am Heart J.
75 Herrington DM, Vittinghoff E, Lin F, Fong J, Harris F, Hunninghake D, Bittner V, Schrott HG, Blumenthal RS, Levy R. (2002). Statin therapy, cardiovascular events, and total mortality in the Heart and Estrogen/Progestin Replacement Study (HERS). Circulation.
76 Hlatky MA, Boothroyd D, Vittinghoff E, Sharp P, Whooley MA. (2002). Quality-of-life and depressive symptoms in postmenopausal women after receiving hormone therapy: results from the Heart and Estrogen/Progestin Replacement Study (HERS) trial. JAMA.
77 Hsia J, Simon JA, Lin F, Applegate WB, Vogt MT, Hunninghake D, Carr M. (2000). Peripheral arterial disease in randomized trial of estrogen with progestin in women with coronary heart disease: the Heart and Estrogen/Progestin Replacement Study. Circulation.
78 Jackson VP, San Martin JA, Secrest RJ, McNabb M, Carranza-Lira S, Figueroa-Casas P, Fernandes CE, Romaguera J. (2003). Comparison of the effect of raloxifene and continuous-combined hormone therapy on mammographic breast density and breast tenderness in postmenopausal women. Am J Obstet Gynecol.
79 Johnston, C. C. Jr; Altman, R. D.; Canfield, R. E.; Finerman, G. A.; Taulbee, J. D., and Ebert, M. L. Review of fracture experience during treatment of Paget's disease of bone with etidronate disodium (EHDP). 1983. Rec #: 1746
80 Kampman E, Giovannucci E, van 't Veer P, Rimm E, Stampfer MJ, Colditz GA, Kok FJ, Willett WC. (1994). Calcium, vitamin D, dairy foods, and the occurrence of colorectal adenomas among men and women in two prospective studies. Am J Epidemiol.
81 Kanaya AM, Herrington D, Vittinghoff E, Lin F, Grady D, Bittner V, Cauley JA, Barrett-Connor E. (2003). Glycemic effects of postmenopausal hormone therapy: the Heart and Estrogen/progestin Replacement Study. A randomized, double-blind, placebo-controlled trial. Ann Intern Med.
82 Kanis JA. (1996). Rationale for the use of bisphosphonates in breast cancer. Acta Oncol.
83 Kohno N, Aogi K, Minami H, Nakamura S, Asaga T, Iino Y, Watanabe T, Goessl C, Ohashi Y, Takashima S. (2005). Zoledronic acid significantly reduces skeletal complications compared with placebo in Japanese women with bone metastases from breast cancer: a randomized, placebo-controlled trial. J Clin Oncol.
84 Kristensen B, Ejlertsen B, Mouridsen HT, Andersen KW, Lauritzen JB. (1996). Femoral fractures in postmenopausal breast cancer patients treated with adjuvant tamoxifen. Breast Cancer Research and Treatment.
85 Lanza F, Rack MF, Simon TJ, Lombardi A, Reyes R, Suryawanshi S. (1998). Effects of alendronate on gastric and duodenal mucosa. Am J Gastroenterol.
86 Lanza F, Sahba B, Schwartz H, Winograd S, Torosis J, Quan H, Reyes R, Musliner T, Daifotis A, Leung A. (2002). The upper GI safety and tolerability of oral alendronate at a dose of 70 milligrams once weekly: a placebo-controlled endoscopy study. Am J Gastroenterol.
87 Lanza F, Schwartz H, Sahba B, Malaty HM, Musliner T, Reyes R, Quan H, Graham DY. (2000). An endoscopic comparison of the effects of alendronate and risedronate on upper gastrointestinal mucosae. Am J Gastroenterol.
88 Lanza FL, Hunt RH, Thomson AB, Provenza JM, Blank MA. (2000). Endoscopic comparison of esophageal and gastroduodenal effects of risedronate and alendronate in postmenopausal women. Gastroenterology.
89 Lanza FL, Rack MF, Li Z, Krajewski SA, Blank MA. (2000). Placebo-controlled, randomized, evaluator-blinded endoscopy study of risedronate vs. aspirin in healthy postmenopausal women. Alimentary Pharmacology & Therapeutics.
90 Lasco A, Cannavo S, Gaudio A, Morabito N, Basile G, Nicita-Mauro V, Frisina N. (2002). Effects of long-lasting raloxifene treatment on serum prolactin and gonadotropin levels in postmenopausal women. Eur J Endocrinol.
91 Lee YS, Low SL, Lim LA, Loke KY. (2001). Cyclic pamidronate infusion improves bone mineralisation and reduces fracture incidence in osteogenesis imperfecta. Eur J Pediatr.
92 Lehmann HJ, Mouritzen U, Christgau S, Cloos PA, Christiansen C. (2002). Effect of bisphosphonates on cartilage turnover assessed with a newly developed assay for collagen type II degradation products. Annals of the Rheumatic Diseases.
93 Leslie WD, Cowden EA, Maclean JP. (1995). Oestrogen and bone density: a comparison of tamoxifen and hypo-oestrogenaemia. Nucl Med Commun.
94 Lethaby, A.; Suckling, J.; Barlow, D.; Farquhar, C. M.; Jepson, R. G., and Roberts, H. Hormone replacement therapy in postmenopausal women. Cochrane Database of Systematic Reviews. 2005(3). Rec #: 1143
95 Lieberman DA, Prindiville S, Weiss DG, Willett W. (2003). Risk factors for advance colonic neoplasia and hyperplastic polyps in asymptomatic individuals. JAMA.
96 Lipton A, Zheng M, Seaman J. (2003). Zoledronic acid delays the onset of skeletal-related events and progression of skeletal disease in patients with advanced renal cell carcinoma. Cancer.
97 Love RR, Newcomb PA, Wiebe DA, Surawicz TS, Jordan VC, Carbone PP, DeMets DL. (1990). Effects of tamoxifen therapy on lipid and lipoprotein levels in postmenopausal patients with node-negative breast cancer. J Natl Cancer Inst.
98 Lowe CE, Depew WT, Vanner SJ, Paterson WG, Meddings JB. (2000). Upper gastrointestinal toxicity of alendronate. The American Journal of Gastroenterology.
99 Marshall JK, Rainsford KD, James C, Hunt RH. (2000). A randomized controlled trial to assess alendronate-associated injury of the upper gastrointestinal tract. Alimentary Pharmacology & Therapeutics.
100 Martino S, Cauley JA, Barrett-Connor E, Powles TJ, Mershon J, Disch D, Secrest RJ, Cummings SR. (2004). Continuing outcomes relevant to Evista: breast cancer incidence in postmenopausal osteoporotic women in a randomized trial of raloxifene. J Natl Cancer Inst.
101 Melnikow J, Paterniti D, Azari R, Kuenneth C, Birch S, Kuppermann M, Nuovo J, Keyzer J, Henderson S. (2005). Preferences of Women Evaluating Risks of Tamoxifen (POWER) study of preferences for tamoxifen for breast cancer risk reduction. Cancer.
102 Menssen HD, Sakalova A, Fontana A, Herrmann Z, Boewer C, Facon T, Lichinitser MR, Singer CR, Euller-Ziegler L, Wetterwald M, Fiere D, Hrubisko M, Thiel E, Delmas PD. (2002). Effects of long-term intravenous ibandronate therapy on skeletal-related events, survival, and bone resorption markers in patients with advanced multiple myeloma. Journal of Clinical Oncology : Official Journal of the American Society of Clinical Oncology.
103 Mignogna MD, Fedele S, Lo Russo L, Ciccarelli R, Lo Muzio L. (2006). Case 2. Osteonecrosis of the jaws associated with bisphosphonate therapy. J Clin Oncol.
104 Mijatovic V, Netelenbos C, van der Mooren MJ, de Valk-de Roo GW, Jakobs C, Kenemans P. (1998). Randomized, double-blind, placebo-controlled study of the effects of raloxifene and conjugated equine estrogen on plasma homocysteine levels in healthy postmenopausal women. Fertil Steril.
105 Mijatovic V, van der Mooren MJ, Kenemans P, de Valk-de Roo GW, Netelenbos C. (1999). Raloxifene lowers serum lipoprotein(A) in healthy postmenopausal women: a randomized, double-blind, placebo-controlled comparison with conjugated equine estrogens. Menopause.
106 Mitchell DY, Eusebio RA, Sacco-Gibson NA, Pallone KA, Kelly SC, Nesbitt JD, Brezovic CP, Thompson GA, Powell JH. (2000). Dose-proportional pharmacokinetics of risedronate on single-dose oral administration to healthy volunteers. Journal of Clinical Pharmacology.
107 Modugno F, Ness RB, Ewing S, Cauley JA. (2003). Effect of raloxifene on sexual function in older postmenopausal women with osteoporosis. Obstet Gynecol.
108 Mongiorgi R, Maggi G, Bertocchi G, Moroni A, Rollo G, Gnudi S, Ponziani L, Coppola G. (1992). Influence of calcitonin treatment on the bone structure and mineral content in osteoarthritis. Boll Soc Ital Biol Sper.
109 Moorman PG, Terry PD. (2004). Consumption of diary products and the risk of breast cancer: a review of the literature. Am J Clin Nutr.
110 Mosca L, Harper K, Sarkar S, O'Gorman J, Anderson PW, Cox DA, Barrett-Connor E. (2001). Effect of raloxifene on serum triglycerides in postmenopausal women: influence of predisposing factors for hypertriglyceridemia. Clinical Therapeutics.
111 Muff R, Dambacher MA, Fischer JA. (1991). Formation of neutralizing antibodies during intranasal synthetic salmon calcitonin treatment of postmenopausal osteoporosis. Osteoporos Int.
112 Mukherjee T, Barad D, Turk R, Freeman R. (1996). A randomized, placebo-controlled study on the effect of cyclic intermittent etidronate therapy on the bone mineral density changes associated with six months of gonadotropin-releasing hormone agonist treatment. Am J Obstet Gynecol.
113 Musto P, Falcone A, Sanpaolo G, Bodenizza C, Cascavilla N, Melillo L, Scalzulli PR, Dell'Olio M, La Sala A, Mantuano S, Nobile M, Carella AM. (2003). Pamidronate reduces skeletal events but does not improve progression-free survival in early-stage untreated myeloma: results of a randomized trial. Leuk Lymphoma.
114 Nehme A, Maalouf G, Tricoire JL, Giordano G, Chiron P, Puget J. (2003). [Effect of alendronate on periprosthetic bone loss after cemented primary total hip arthroplasty: a prospective randomized study]. Revue De Chirurgie Orthopedique Et Reparatrice De L'Appareil Moteur.
115 Nishi Y, Hamamoto K, Kajiyama M, Ono H, Kihara M, Jinno K. (1992). Effect of long-term calcitonin therapy by injection and nasal spray on the incidence of fractures in osteogenesis imperfecta. J Pediatr.
116 Norman, R. J.; Flight, I. H. K., and Rees, M. C. P. Oestrogen and progestogen hormone replacement therapy for peri-menopausal and post-menopausal women. Cochrane Database of Systematic Reviews. 2005(3). Rec #: 1138
117 Oglesby AK, Minshall ME, Shen W, Xie S, Silverman SL. (2003). The impact of incident vertebral and non-vertebral fragility fractures on health-related quality of life in established postmenopausal osteoporosis: results from the teriparatide randomized, placebo-controlled trial in postmenopausal women. J Rheumatol.
118 Ogura Y, Gonsho A, Cyong JC, Orimo H. (2004). Clinical trial of risedronate in Japanese volunteers: a study on the effects of timing of dosing on absorption. J Bone Miner Metab.
119 ---. Clinical trial of risedronate in Japanese volunteers: single and multiple oral dose studies. J Bone Miner Metab. 2004; 22(2):111–9. Rec #: 2797
120 Oleksik AM, Duong T, Pliester N, Asma G, Popp-Snijders C, Lips P. (2001). Effects of the selective estrogen receptor modulator, raloxifene, on the somatotropic axis and insulin-glucose homeostasis. The Journal of Clinical Endocrinology and Metabolism.
121 Paganini-Hill A. (1999). Estrogen replacement therapy and colorectal cancer risk in elderly women. Dis Colon Rectum.
122 Palacios S, Farias ML, Luebbert H, Gomez G, Yabur JA, Quail DC, Turbi C, Kayath MJ, Almeida MJ, Monnig E, Nickelsen T. (2004). Raloxifene is not associated with biologically relevant changes in hot flushes in postmenopausal women for whom therapy is appropriate. American Journal of Obstetrics and Gynecology.
123 Pares A, Guanabens N, Monegal A, Peris P, Pons F, Alvarez L, Martinez de Osaba MJ, Roca M, Munoz J, Rodes J. (1995). Cyclical etidronate versus sodium fluoride for treatment of osteopenia in primary biliary cirrhosis. Effects after two-years. Hepatology.
124 Pastor-Zuazaga, D.; Garatea-Crelgo, J.; Martino-Gorbea, R.; Etayo-Perez, A., and Sebastian-Lopez, C. Osteonecrosis of the jaws and bisphosphonates. Report of three cases. Med Oral Patol Oral Cir Bucal. 2006 Jan–2006 Feb 28; 11(1):E76–9. Rec #: 3531
125 Pavlakis, N. and Stockler, M. Bisphosphonates for breast cancer. Cochrane Database Syst Rev. 2002; (1):CD003474. Rec #: 2819
126 Petersen MM, Lauritzen JB, Schwarz P, Lund B. (1998). Effect of nasal salmon calcitonin on post-traumatic osteopenia following ankle fracture. A randomized double-blind placebo-controlled study in 24 patients. Acta Orthopaedica Scandinavica.
127 Pfutzner A, Flacke F, Pohl R, Linkie D, Engelbach M, Woods R, Forst T, Beyer J, Steiner SS. (2003). Pilot study with technosphere/PTH(1–34) - a new approach for effective pulmonary delivery of parathyroid hormone (1–34). Hormone & Metabolic Research.
128 Pilon D, Castilloux AM, LeLorier J. (2001). Estrogen replacement therapy: determinants of persistence with treatment. Obstet Gynecol.
129 Polascik TJ, Given RW, Metzger C, Julian SR, Vestal JC, Karlin GS, Barkley CS, Bilhartz DL, McWhorter LT, Lacerna LV. (2005). Open-label trial evaluating the safety and efficacy of zoledronic acid in preventing bone loss in patients with hormone-sensitive prostate cancer and bone metastases. Urology.
130 Ralston SH, Hacking L, Willocks L, Bruce F, Pitkeathly DA. (1989). Clinical, biochemical, and radiographic effects of aminohydroxypropylidene bisphosphonate treatment in rheumatoid arthritis. Annals of the Rheumatic Diseases.
131 Rauch F, Plotkin H, Travers R, Zeitlin L, Glorieux FH. (2003). Osteogenesis imperfecta types I, III, and IV: effect of pamidronate therapy on bone and mineral metabolism. J Clin Endocrinol Metab.
132 Reginster JY, Gaspar S, Deroisy R, Zegels B, Franchimont P. (1993). Prevention of osteoporosis with nasal salmon calcitonin: effect of anti-salmon calcitonin antibody formation. Osteoporos Int.
133 Resch A, Biber E, Seifert M, Resch H. (1998). Evidence that tamoxifen preserves bone density in late postmenopausal women with breast cancer. Acta Oncol.
134 Ribeiro A, DeVault KR, Wolfe JT, Stark ME. (1998). Alendronate-associated esophagitis: endoscopic and pathologic features. Gastrointest Endosc.
135 Risch, H. A. and Howe, G. R. Menopausal hormone use and colorectal cancer in Saskatchewan: a record linkage cohort study. Cancer Epidemiol Biomarkers Prev. 1995 Jan–1995 Feb 28; 4(1):21–8. Rec #: 3571
136 Rodan GA. (2002). Bisphosphonates and primary hyperparathyroidism. J Bone Miner Res.
137 Rosen HN, Moses AC, Gundberg C, Kung VT, Seyedin SM, Chen T, Holick M, Greenspan SL. (1993). Therapy with parenteral pamidronate prevents thyroid hormone-induced bone turnover in humans. J Clin Endocrinol Metab.
138 Rosen LS, Gordon D, Kaminski M, Howell A, Belch A, Mackey J, Apffelstaedt J, Hussein MA, Coleman RE, Reitsma DJ, Chen BL, Seaman JJ. (2003). Long-term efficacy and safety of zoledronic acid compared with pamidronate disodium in the treatment of skeletal complications in patients with advanced multiple myeloma or breast carcinoma: a randomized, double-blind, multicenter, comparative trial. Cancer.
139 Ross, JR; Saunders, Y; Edmonds, PM; Patel, S; Broadley, KE, and Johnston, SRD. Systematic review of role of bisphosphonates on skeletal morbidity in metastatic cancer. BMJ. 2006 Nov 13; (2). Rec #: 3253
140 Saad F. (2005). Clinical benefit of zoledronic acid for the prevention of skeletal complications in advanced prostate cancer. Clin Prostate Cancer.
141 Saad F, Gleason DM, Murray R, Tchekmedyian S, Venner P, Lacombe L. (2002). A randomized, placebo-controlled trial of zoledronic acid in patients with hormone-refractory metastatic prostate carcinoma. J Natl Cancer Inst.
142 Sacco M, Valentini M, Belfiglio M, Pellegrini F, De Berardis G, Franciosi M, Nicolucci A. (2003). Randomized trial of 2 versus 5 years of adjuvant tamoxifen for women aged 50 years or older with early breast cancer: Italian Interdisciplinary Group Cancer Evaluation Study of Adjuvant Treatment in Breast Cancer 01. J Clin Oncol.
143 Sarno M, Sarno L, Baylink D, Drinkwater B, Farley S, Kleerekoper M, Lang R, Lappe J, Licata A, McClung M, Miller P, Nattrass S, Recker R, Schwartz EN, Tucci JR, Wolf S, Powell H, Tjersland G, Warnick GR. (2001). Excretion of sweat and urine pyridinoline crosslinks in healthy controls and subjects with established metabolic bone disease. Clinical Chemistry and Laboratory Medicine : CCLM / FESCC.
144 Saunders RL. (1977). Appearance of a gastric ulcer during diphosphonate therapy in a woman with CRST syndrome. South Med J.
145 Shapiro JR, McCarthy EF, Rossiter K, Ernest K, Gelman R, Fedarko N, Santiago HT, Bober M. (2003). The effect of intravenous pamidronate on bone mineral density, bone histomorphometry, and parameters of bone turnover in adults with type IA osteogenesis imperfecta. Calcif Tissue Int.
146 Shapiro S. (2003). Risks of estrogen plus progestin therapy: a sensitivity analysis of findings in the Women's Health Initiative randomized controlled trial. Climacteric.
147 Shlipak MG, Chaput LA, Vittinghoff E, Lin F, Bittner V, Knopp RH, Hulley SB. (2003). Lipid changes on hormone therapy and coronary heart disease events in the Heart and Estrogen/progestin Replacement Study (HERS). Am Heart J.
148 Shlipak MG, Simon JA, Vittinghoff E, Lin F, Barrett-Connor E, Knopp RH, Levy RI, Hulley SB. (2000). Estrogen and progestin, lipoprotein(a), and the risk of recurrent coronary heart disease events after menopause. JAMA.
149 Shumaker SA, Legault C, Kuller L, Rapp SR, Thal L, Lane DS, Fillit H, Stefanick ML, Hendrix SL, Lewis CE, Masaki K, Coker LH. (2004). Conjugated equine estrogens and incidence of probable dementia and mild cognitive impairment in postmenopausal women: Women's Health Initiative Memory Study. JAMA.
150 Shumaker SA, Legault C, Rapp SR, Thal L, Wallace RB, Ockene JK, Hendrix SL, Jones BN, Assaf AR, Jackson RD, Kotchen JM, Wassertheil-Smoller S, Wactawski-Wende J. (2003). Estrogen plus progestin and the incidence of dementia and mild cognitive impairment in postmenopausal women: the Women's Health Initiative Memory Study: a randomized controlled trial. JAMA.
151 Simberg N, Tiitinen A, Silfvast A, Viinikka L, Ylikorkala O. (1996). High bone density in hyperandrogenic women: effect of gonadotropin-releasing hormone agonist alone or in conjunction with estrogen-progestin replacement. J Clin Endocrinol Metab.
152 Simon JA, Hsia J, Cauley JA, Richards C, Harris F, Fong J, Barrett-Connor E, Hulley SB. (2001). Postmenopausal hormone therapy and risk of stroke: The Heart and Estrogen-progestin Replacement Study (HERS). Circulation.
153 Small EJ, Smith MR, Seaman JJ, Petrone S, Kowalski MO. (2003). Combined analysis of two multicenter, randomized, placebo-controlled studies of pamidronate disodium for the palliation of bone pain in men with metastatic prostate cancer. Journal of Clinical Oncology : Official Journal of the American Society of Clinical Oncology.
154 Smith MR. (2003). Bisphosphonates to prevent skeletal complications in men with metastatic prostate cancer. J Urol.
155 Soininvaara TA, Jurvelin JS, Miettinen HJ, Suomalainen OT, Alhava EM, Kroger PJ. (2002). Effect of alendronate on periprosthetic bone loss after total knee arthroplasty: a one-year, randomized, controlled trial of 19 patients. Calcified Tissue International.
156 Solomon DH, Katz JN, Jacobs JP, La Tourette AM, Coblyn J. (2002). Management of glucocorticoid-induced osteoporosis in patients with rheumatoid arthritis: rates and predictors of care in an academic rheumatology practice. Arthritis Rheum.
157 Ste-Marie LG, Sod E, Johnson T, Chines A. (2004). Five years of treatment with risedronate and its effects on bone safety in women with postmenopausal osteoporosis. Calcif Tissue Int.
158 Surrey ES, Fournet N, Voigt B, Judd HL. (1993). Effects of sodium etidronate in combination with low-dose norethindrone in patients administered a long-acting GnRH agonist: a preliminary report. Obstet Gynecol.
159 Terpos E, Viniou N, de la Fuente J, Meletis J, Voskaridou E, Karkantaris C, Vaiopoulos G, Palermos J, Yataganas X, Goldman JM, Rahemtulla A. (2003). Pamidronate is superior to ibandronate in decreasing bone resorption, interleukin-6 and beta 2-microglobulin in multiple myeloma. European Journal of Haematology.
160 Thomson AB, Marshall JK, Hunt RH, Provenza JM, Lanza FL, Royer MG, Li Z, Blank MA. (2002). 14 day endoscopy study comparing risedronate and alendronate in postmenopausal women stratified by Helicobacter pylori status. The Journal of Rheumatology.
161 Thomson, A. B. R.; Hunt, R. H., and Lanza, F. L. Risedronate has significantly lower incidence of gastric ulcers compared to alendronate. 2000; 118, (4 suppl 2): A474. Rec #: 3145
162 Tommaselli, G. A.; Di Carlo, C.; Di Spiezio Sardo, A.; Bifulco, G.; Cirillo, D.; Guida, M.; Capasso, R., and Nappi, C. Serum leptin levels and body composition in postmenopausal women treated with tibolone and raloxifene. Menopause. 2006 Jul–2006 Aug 31; 13(4):660–8. Rec #: 3551
163 Tralongo P, Repetto L, Di Mari A, Mauceri G, Bollina R, Ferrau' F, Conti G. (2004). Safety of long-term administration of bisphosphonates in elderly cancer patients. Oncology.
164 Turken S, Siris E, Seldin D, Flaster E, Hyman G, Lindsay R. (1989). Effects of tamoxifen on spinal bone density in women with breast cancer. J Natl Cancer Inst.
165 Twiss IM, van den Berk AH, de Kam ML, Bosch JJ, Cohen AF, Vermeij P, Burggraaf J. (2006). A comparison of the gastrointestinal effects of the nitrogen-containing bisphosphonates pamidronate, alendronate, and olpadronate in humans. J Clin Pharmacol.
166 Ulrich U, Browning M, Gaffney EV, Schoter KH, Chesnut CH. (1997). Implementation of an osteoporosis research program with a mobile dual-energy X-ray absorptiometry unit: the Montana/Wyoming experience. Osteoporosis International : A Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
167 Unson CG, Litt M, Reisine S, Mahoney-Trella P, Sheperd T, Prestwood K. (2006). Adherence to calcium/vitamin D and estrogen protocols among diverse older participants enrolled in a clinical trial. Contemp Clin Trials.
168 Valleala H, Mandelin J, Laasonen L, Koivula MK, Risteli J, Konttinen YT. (2003). Effect of cyclical intermittent etidronate therapy on circulating osteoprotegerin levels in patients with rheumatoid arthritis. European Journal of Endocrinology / European Federation of Endocrine Societies.
169 Vincenzi B, Santini D, Dicuonzo G, Battistoni F, Gavasci M, La Cesa A, Grilli C, Virzi V, Gasparro S, Rocci L, Tonini G. (2005). Zoledronic acid-related angiogenesis modifications and survival in advanced breast cancer patients. J Interferon Cytokine Res.
170 Vittinghoff E, Shlipak MG, Varosy PD, Furberg CD, Ireland CC, Khan SS, Blumenthal R, Barrett-Connor E, Hulley S. (2003). Risk factors and secondary prevention in women with heart disease: the Heart and Estrogen/progestin Replacement Study. Ann Intern Med.
171 Vogel VG, Costantino JP, Wickerham DL, Cronin WM, Wolmark N. (2002). The study of tamoxifen and raloxifene: preliminary enrollment data from a randomized breast cancer risk reduction trial. Clin Breast Cancer.
172 Walsh BW, Kuller LH, Wild RA, Paul S, Farmer M, Lawrence JB, Shah AS, Anderson PW. (1998). Effects of raloxifene on serum lipids and coagulation factors in healthy postmenopausal women. JAMA.
173 Walsh BW, Paul S, Wild RA, Dean RA, Tracy RP, Cox DA, Anderson PW. (2000). The effects of hormone replacement therapy and raloxifene on C-reactive protein and homocysteine in healthy postmenopausal women: a randomized, controlled trial. J Clin Endocrinol Metab.
174 Wang CJ, Wang JW, Weng LH, Hsu CC, Huang CC, Chen HS. (2003). The effect of alendronate on bone mineral density in the distal part of the femur and proximal part of the tibia after total knee arthroplasty. The Journal of Bone and Joint Surgery American Volume.
175 Whyte MP, Wenkert D, Clements KL, McAlister WH, Mumm S. (2003). Bisphosphonate-induced osteopetrosis. N Engl J Med.
176 Winer KK, Ko CW, Reynolds JC, Dowdy K, Keil M, Peterson D, Gerber LH, McGarvey C, Cutler GB. (2003). Long-term treatment of hypoparathyroidism: a randomized controlled study comparing parathyroid hormone-(1–34) versus calcitriol and calcium. J Clin Endocrinol Metab.
177 Woo SB, Hellstein JW, Kalmar JR. (2006). Systematic review: bisphosphonates and osteonecrosis of the jaws. Ann Intern Med.
178 Yaffe K, Krueger K, Cummings SR, Blackwell T, Henderson VW, Sarkar S, Ensrud K, Grady D. (2005). Effect of raloxifene on prevention of dementia and cognitive impairment in older women: the Multiple Outcomes of Raloxifene Evaluation (MORE) randomized trial. Am J Psychiatry.
179 Yalcin B, Buyukcelik A, Yalcin S, Utkan G, Doruk H, Dogan M, Altan M. (2005). Re: Continuing outcomes relevant to Evista: breast cancer incidence in postmenopausal osteoporotic women in a randomized trial of raloxifene. J Natl Cancer Inst.
180 Zylberberg B, Dormont D, Perrot N, Uzan S. (1993). Breast cancer: effect of tamoxifen on the mineral density of bone. Eur J Obstet Gynecol Reprod Biol.

## REJECTED: Covered in previous meta-analysis

1 Abellan PM, Bayina GFJ, Calabozo M, Carpintero BP, Figueroa PM, Fernandez CMC, Garcia LA, Garcia PS, Mesa RM, Paulino TJ, Rodriguez PM, Salazar VJM, Valenzuela CA, Povedano GJ, Sanchez TA. (1995). Multicentric comparative study of synthetic salmon calcitonin nasally administered in the treatment of established postmenopausic osteoporosis. Anales De Medicina Interna.
2 Adachi JD, Bensen WG, Brown J, Hanley D, Hodsman A, Josse R, Kendler DL, Lentle B, Olszynski W, Ste-Marie LG, Tenenhouse A, Chines AA. (1997). Intermittent etidronate therapy to prevent corticosteroid-induced osteoporosis. N Engl J Med.
3 Adachi JD, Saag KG, Delmas PD, Liberman UA, Emkey RD, Seeman E, Lane NE, Kaufman JM, Poubelle PE, Hawkins F, Correa-Rotter R, Menkes CJ, Rodriguez-Portales JA, Schnitzer TJ, Block JA, Wing J, McIlwain HH, Westhovens R, Brown J, Melo-Gomes JA, Gruber BL, Yanover MJ, Leite MO, Siminoski KG, Nevitt MC, Sharp JT, Malice MP, Dumortier T, Czachur M, Carofano W, Daifotis A. (2001). Two-year effects of alendronate on bone mineral density and vertebral fracture in patients receiving glucocorticoids: a randomized, double-blind, placebo-controlled extension trial. Arthritis Rheum.
4 Alexandersen P, Riis BJ, Christiansen C. (1999). Monofluorophosphate combined with hormone replacement therapy induces a synergistic effect on bone mass by dissociating bone formation and resorption in postmenopausal women: a randomized study. J Clin Endocrinol Metab.
5 Aloia JF, Vaswani A, Kapoor A, Yeh JK, Cohn SH. (1985). Treatment of osteoporosis with calcitonin, with and without growth hormone. Metabolism.
6 Anderson GL, Limacher M, Assaf AR, Bassford T, Beresford SA, Black H, Bonds D, Brunner R, Brzyski R, Caan B, Chlebowski R, Curb D, Gass M, Hays J, Heiss G, Hendrix S, Howard BV, Hsia J, Hubbell A, Jackson R, Johnson KC, Judd H, Kotchen JM, Kuller L, LaCroix AZ, Lane D, Langer RD, Lasser N, Lewis CE, Manson J, Margolis K, Ockene J, O'Sullivan MJ, Phillips L, Prentice RL, Ritenbaugh C, Robbins J, Rossouw JE, Sarto G, Stefanick ML, Van Horn L, Wactawski-Wende J, Wallace R, Wassertheil-Smoller S. (2004). Effects of conjugated equine estrogen in postmenopausal women with hysterectomy: the Women's Health Initiative randomized controlled trial. JAMA.
7 Aris RM, Lester GE, Caminiti M, Blackwood AD, Hensler M, Lark RK, Hecker TM, Renner JB, Guillen U, Brown SA, Neuringer IP, Chalermskulrat W, Ontjes DA. (2004). Efficacy of alendronate in adults with cystic fibrosis with low bone density. Am J Respir Crit Care Med.
8 Ascott-Evans BH, Guanabens N, Kivinen S, Stuckey BG, Magaril CH, Vandormael K, Stych B, Melton ME. (2003). Alendronate prevents loss of bone density associated with discontinuation of hormone replacement therapy: a randomized controlled trial. Arch Intern Med.
9 Bauer DC, Black D, Ensrud K, Thompson D, Hochberg M, Nevitt M, Musliner T, Freedholm D. (2000). Upper gastrointestinal tract safety profile of alendronate: the fracture intervention trial. Arch Intern Med.
10 Bauer DC, Black DM, Garnero P, Hochberg M, Ott S, Orloff J, Thompson DE, Ewing SK, Delmas PD. (2004). Change in bone turnover and hip, non-spine, and vertebral fracture in alendronate-treated women: the fracture intervention trial. J Bone Miner Res.
11 Biermasz NR, Hamdy NA, Janssen YJ, Roelfsema F. (2001). Additional beneficial effects of alendronate in growth hormone (GH)-deficient adults with osteoporosis receiving long-term recombinant human GH replacement therapy: a randomized controlled trial. The Journal of Clinical Endocrinology and Metabolism.
12 Bjarnason NH, Sarkar S, Duong T, Mitlak B, Delmas PD, Christiansen C. (2001). Six and twelve month changes in bone turnover are related to reduction in vertebral fracture risk during 3 years of raloxifene treatment in postmenopausal osteoporosis. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
13 Black D, Schwartz A, Ensrud K, et al. (2004). A 5-year randomized trial of the long-term efficacy and safety of alendronate: The FIT Long-Term Extension (FLEX). J Bone Miner Res.
14 Black D, Thompson D, Quandt S. (2002). Aledronate reduces risk of vertebral fracture in women with BMD T-scores above -2.5: results from the Fracture Intervention Trial (FIT). J Bone Miner Res.
15 Black DM, Cummings SR, Karpf DB, Cauley JA, Thompson DE, Nevitt MC, Bauer DC, Genant HK, Haskell WL, Marcus R, Ott SM, Torner JC, Quandt SA, Reiss TF, Ensrud KE. (1996). Randomised trial of effect of alendronate on risk of fracture in women with existing vertebral fractures. Fracture Intervention Trial Research Group. Lancet.
16 Bone HG, Downs RW, Tucci JR, Harris ST, Weinstein RS, Licata AA, McClung MR, Kimmel DB, Gertz BJ, Hale E, Polvino WJ. (1997). Dose-response relationships for alendronate treatment in osteoporotic elderly women. Alendronate Elderly Osteoporosis Study Centers. J Clin Endocrinol Metab.
17 Bone HG, Hosking D, Devogelaer JP, Tucci JR, Emkey RD, Tonino RP, Rodriguez-Portales JA, Downs RW, Gupta J, Santora AC, Liberman UA. (2004). Ten years' experience with alendronate for osteoporosis in postmenopausal women. N Engl J Med.
18 Brown JP, Olszynski WP, Hodsman A, Bensen WG, Tenenhouse A, Anastassiades TP, Ste-Marie LG, Kendler DL, Hanley DA, Josse R, Hanly JG, Lentle B, Jovaisas A, Ioannidis G, Stephenson GF, Barton I, Pack S, Chines A, Dias R, Adachi JD. (2001). Positive effect of etidronate therapy is maintained after drug is terminated in patients using corticosteroids. Journal of Clinical Densitometry : the Official Journal of the International Society for Clinical Densitometry.
19 Brumsen C, Papapoulos SE, Lips P, Geelhoed-Duijvestijn PH, Hamdy NA, Landman JO, McCloskey EV, Netelenbos JC, Pauwels EK, Roos JC, Valentijn RM, Zwinderman AH. (2002). Daily oral pamidronate in women and men with osteoporosis: a 3-year randomized placebo-controlled clinical trial with a 2-year open extension. J Bone Miner Res.
20 Cauley JA, Black DM, Barrett-Connor E, Harris F, Shields K, Applegate W, Cummings SR. (2001). Effects of hormone replacement therapy on clinical fractures and height loss: The Heart and Estrogen/Progestin Replacement Study (HERS). Am J Med.
21 Cauley JA, Robbins J, Chen Z, Cummings SR, Jackson RD, LaCroix AZ, LeBoff M, Lewis CE, McGowan J, Neuner J, Pettinger M, Stefanick ML, Wactawski-Wende J, Watts NB. (2003). Effects of estrogen plus progestin on risk of fracture and bone mineral density: the Women's Health Initiative randomized trial. JAMA.
22 Chapurlat RD, Ewing SK, Bauer DC, Cummings SR. (2001). Influence of smoking on the antiosteoporotic efficacy of raloxifene. The Journal of Clinical Endocrinology and Metabolism.
23 Chapuy MC, Pamphile R, Paris E, Kempf C, Schlichting M, Arnaud S, Garnero P, Meunier PJ. (2002). Combined calcium and vitamin D3 supplementation in elderly women: confirmation of reversal of secondary hyperparathyroidism and hip fracture risk: the Decalyos II study. Osteoporos Int.
24 Cherry, N.; Gilmour, K.; Hannaford, P.; Heagerty, A.; Khan, M. A.; Kitchener, H.; McNamee, R.; Elstein, M.; Kay, C.; Seif, M., and Buckley, H. Oestrogen therapy for prevention of reinfarction in postmenopausal women: a randomised placebo controlled trial. Lancet. 2002 Dec 21–2002 Dec 28; 360(9350):2001–8. Rec #: 3192
25 Chesnut CH, McClung MR, Ensrud KE, Bell NH, Genant HK, Harris ST, Singer FR, Stock JL, Yood RA, Delmas PD. (1995). Alendronate treatment of the postmenopausal osteoporotic woman: effect of multiple dosages on bone mass and bone remodeling. The American Journal of Medicine.
26 Chesnut CH, Silverman S, Andriano K, Genant H, Gimona A, Harris S, Kiel D, LeBoff M, Maricic M, Miller P, Moniz C, Peacock M, Richardson P, Watts N, Baylink D. (2000). A randomized trial of nasal spray salmon calcitonin in postmenopausal women with established osteoporosis: the prevent recurrence of osteoporotic fractures study. PROOF Study Group. Am J Med.
27 Clemmesen B, Ravn P, Zegels B, Taquet AN, Christiansen C, Reginster JY. (1997). A 2-year phase II study with 1-year of follow-up of risedronate (NE-58095) in postmenopausal osteoporosis. Osteoporos Int.
28 Cohen S, Levy RM, Keller M, Boling E, Emkey RD, Greenwald M, Zizic TM, Wallach S, Sewell KL, Lukert BP, Axelrod DW, Chines AA. (1999). Risedronate therapy prevents corticosteroid-induced bone loss: a twelve-month, multicenter, randomized, double-blind, placebo-controlled, parallel-group study. Arthritis Rheum.
29 Cortet B, Hachulla E, Barton I, Bonvoisin B, Roux C. (1999). Evaluation of the efficacy of etidronate therapy in preventing glucocorticoid-induced bone loss in patients with inflammatory rheumatic diseases. A randomized study. Rev Rhum Engl Ed.
30 Cremer J, Struber M, Wagenbreth I, Nischelsky J, Demertzis S, Graeter T, Abraham C, Haverich A. (1999). Progression of steroid-associated osteoporosis after heart transplantation. The Annals of Thoracic Surgery.
31 Cummings, S. R.; Black, D. M.; Thompson, D. E.; Applegate, W. B.; Barrett-Connor, E.; Musliner, T. A.; Palermo, L.; Prineas, R.; Rubin, S. M.; Scott, J. C.; Vogt, T.; Wallace, R.; Yates, A. J., and LaCroix, A. Z. Effect of alendronate on risk of fracture in women with low bone density but without vertebral fractures: results from the Fracture Intervention Trial. JAMA. 1998 Dec 23–1998 Dec 30; 280(24):2077–82. Rec #: 1116
32 Daufmann J. (2001). Recombinant human parathyroid hormone therapy (1–34) increases bone mineral density and may decrease the risk of fractures in men with low bone density. Osteoporosis International.
33 Delmas PD, Ensrud KE, Adachi JD, Harper KD, Sarkar S, Gennari C, Reginster JY, Pols HA, Recker RR, Harris ST, Wu W, Genant HK, Black DM, Eastell R. (2002). Efficacy of raloxifene on vertebral fracture risk reduction in postmenopausal women with osteoporosis: four-year results from a randomized clinical trial. J Clin Endocrinol Metab.
34 Delmas PD, Genant HK, Crans GG, Stock JL, Wong M, Siris E, Adachi JD. (2003). Severity of prevalent vertebral fractures and the risk of subsequent vertebral and nonvertebral fractures: results from the MORE trial. Bone.
35 Devogelaer JP, Broll H, Correa-Rotter R, Cumming DC, De Deuxchaisnes CN, Geusens P, Hosking D, Jaeger P, Kaufman JM, Leite M, Leon J, Liberman U, Menkes CJ, Meunier PJ, Reid I, Rodriguez J, Romanowicz A, Seeman E, Vermeulen A, Hirsch LJ, Lombardi A, Plezia K, Santora AC, Yates AJ, Yuan W. (1996). Oral alendronate induces progressive increases in bone mass of the spine, hip, and total body over 3 years in postmenopausal women with osteoporosis. Bone.
36 Downs RW, Bone HG, McIlwain H, Baker MZ, Yates AJ, Lombardi A, Krupa D, Harning R. (1999). An open-label extension study of alendronate treatment in elderly women with osteoporosis. Calcif Tissue Int.
37 Drake WM, Brown JP, Banville C, Kendler DL. (2002). Use of phalangeal bone mineral density and multi-site speed of sound conduction to monitor therapy with alendronate in postmenopausal women. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
38 Drake WM, Kendler DL, Rosen CJ, Orwoll ES. (2003). An investigation of the predictors of bone mineral density and response to therapy with alendronate in osteoporotic men. J Clin Endocrinol Metab.
39 Eastell R, Adachi J, Harper K, Sarkar S, Delmas PD, Ensrud K, et al. (2000). The effects of raloxifene on incident vertebral fractures in postmenopausal women with osteoporosis: 4-year results from the MORE trial [abstract]. J Bone Min Res.
40 Eastell R, Devogelaer JP, Peel NF, Chines AA, Bax DE, Sacco-Gibson N, Nagant de Deuxchaisnes C, Russell RG. (2000). Prevention of bone loss with risedronate in glucocorticoid-treated rheumatoid arthritis patients. Osteoporos Int.
41 Eastell, R.; Minne, I. I.; Sorensen, O.; Shooper, M.; Ritter-Hnacrick, C.; Pack, S.; Roumagnac, I.; Ethgen, D., and Reginster, J. Y. Risedronate reduces fracture risk in women with established postmenopausal osteoporosis. Calcified Tissue International. 1999; 0–25. Rec #: 3095
42 Ensrud K, Black D, Recker R, Harris S, Delmas P, Pols H, et al. (1998). The effect of 2 and 3 years of raloxifene on vertabral and non-vertebral fractures in postmenapausal women with osteoporosis [abstract]. Bone.
43 Ensrud, K. E.; Black, D. M.; Palermo, L.; Bauer, D. C. ; Barrett-Connor, E.; Quandt, S. A.; Thompson, D. E., and Karpf, D. B. Treatment with alendronate prevents fractures in women at highest risk: results from the Fracture Intervention Trial. Arch Intern Med. 1997 Dec 8–1997 Dec 22; 157(22):2617–24. Rec #: 1115
44 Ettinger B, Black D, Cummings S, Genant H, Gluer C, Lips P. (1998). Raloxifene reduces the risk of incident vertebral fractures: 24 month interim analyses [abstract]. Osteoporos Int.
45 Ettinger B, Black DM, Mitlak BH, Knickerbocker RK, Nickelsen T, Genant HK, Christiansen C, Delmas PD, Zanchetta JR, Stakkestad J, Gluer CC, Krueger K, Cohen FJ, Eckert S, Ensrud KE, Avioli LV, Lips P, Cummings SR. (1999). Reduction of vertebral fracture risk in postmenopausal women with osteoporosis treated with raloxifene: results from a 3-year randomized clinical trial. Multiple Outcomes of Raloxifene Evaluation (MORE) Investigators. JAMA.
46 Fink HA, Ensrud KE, Nelson DB, Kerani RP, Schreiner PJ, Zhao Y, Cummings SR, Nevitt MC. (2003). Disability after clinical fracture in postmenopausal women with low bone density: the fracture intervention trial (FIT). Osteoporos Int.
47 Fogelman I, Ribot C, Smith R, Ethgen D, Sod E, Reginster JY. (2000). Risedronate reverses bone loss in postmenopausal women with low bone mass: results from a multinational, double-blind, placebo-controlled trial. BMD-MN Study Group. J Clin Endocrinol Metab.
48 Fujita T, Inoue T, Morii H, Morita R, Norimatsu H, Orimo H, Takahashi HE, Yamamoto K, Fukunaga M. (1999). Effect of an intermittent weekly dose of human parathyroid hormone (1–34) on osteoporosis: a randomized double-masked prospective study using three dose levels. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
49 Gennari, C.; Chierichetti, S. M.; Bigazzi, S., and et al. Comparative effects on bone mineral content of calcium and calcium plus salmon calcitonin given in two different regimens in postmenopausal osteoporosis. Curr. 1985; THER. RES., CLIN. EXP. 38(3):455–464. Rec #: 1977
50 Geusens P, Dequeker J, Vanhoof J, Stalmans R, Boonen S, Joly J, Nijs J, Raus J. (1998). Cyclical etidronate increases bone density in the spine and hip of postmenopausal women receiving long term corticosteroid treatment. A double blind, randomised placebo controlled study. Ann Rheum Dis.
51 Geusens P, Vanhoof J, Stalmans R, Joly J, Dequeker J, Nijs J, Rauss J. (1997). Cyclic etidronate increases bone density in the spine and hip in postmenopausal women on chronic corticosteroid treatment. A double-blind controlled study. Bone.
52 Greendale GA, Espeland M, Slone S, Marcus R, Barrett-Connor E. (2002). Bone mass response to discontinuation of long-term hormone replacement therapy: results from the Postmenopausal Estrogen/Progestin Interventions (PEPI) Safety Follow-up Study. Arch Intern Med.
53 Greenspan SL, Schneider DL, McClung MR, Miller PD, Schnitzer TJ, Bonin R, Smith ME, DeLucca P, Gormley GJ, Melton ME. (2002). Alendronate improves bone mineral density in elderly women with osteoporosis residing in long-term care facilities. A randomized, double-blind, placebo-controlled trial.[summary for patients in Ann Intern Med. 2002 May 21;136(10):I54; PMID: 12020160]. Annals of Internal Medicine.
54 Guanabens N, Farrerons J, Perez-Edo L, Monegal A, Renau A, Carbonell J, Roca M, Torra M, Pavesi M. (2000). Cyclical etidronate versus sodium fluoride in established postmenopausal osteoporosis: a randomized 3 year trial. Bone.
55 Guaraldi G, Orlando G, Madeddu G, Vescini F, Ventura P, Campostrini S, Mura MS, Parise N, Caudarella R, Esposito R. (2004). Alendronate reduces bone resorption in HIV-associated osteopenia/osteoporosis. HIV Clinical Trials.
56 Gutteridge DH, Holzherr ML, Retallack RW, Price RI, Will RK, Dhaliwal SS, Faulkner DL, Stewart GO, Stuckey BG, Prince RL, Criddle RA, Drury PJ, Tran L, Bhagat CI, Kent GN, Jamrozik K. (2003). A randomized trial comparing hormone replacement therapy (HRT) and HRT plus calcitriol in the treatment of postmenopausal osteoporosis with vertebral fractures: benefit of the combination on total body and hip density. Calcified Tissue International.
57 Gutteridge DH, Stewart GO, Prince RL, Price RI, Retallack RW, Dhaliwal SS, Stuckey BG, Drury P, Jones CE, Faulkner DL, Kent GN, Bhagat CI, Nicholson GC, Jamrozik K. (2002). A randomized trial of sodium fluoride (60 mg) +/- estrogen in postmenopausal osteoporotic vertebral fractures: increased vertebral fractures and peripheral bone loss with sodium fluoride; concurrent estrogen prevents peripheral loss, but not vertebral fractures. Osteoporos Int.
58 Haderslev KV, Tjellesen L, Sorensen HA, Staun M. (2000). Alendronate increases lumbar spine bone mineral density in patients with Crohn's disease. Gastroenterology.
59 Harris ST, Watts NB, Genant HK, McKeever CD, Hangartner T, Keller M, Chesnut CH, Brown J, Eriksen EF, Hoseyni MS, Axelrod DW, Miller PD. (1999). Effects of risedronate treatment on vertebral and nonvertebral fractures in women with postmenopausal osteoporosis: a randomized controlled trial. Vertebral Efficacy With Risedronate Therapy (VERT) Study Group. JAMA.
60 Harris ST, Watts NB, Jackson RD, Genant HK, Wasnich RD, Ross P, Miller PD, Licata AA, Chesnut CH. (1993). Four-year study of intermittent cyclic etidronate treatment of postmenopausal osteoporosis: three years of blinded therapy followed by one year of open therapy. Am J Med.
61 Harwood RH, Sahota O, Gaynor K, Masud T, Hosking DJ. (2004). A randomised, controlled comparison of different calcium and vitamin D supplementation regimens in elderly women after hip fracture: The Nottingham Neck of Femur (NONOF) Study. Age Ageing.
62 Hay JE, Dickson ER, Khosla S, Wiesner R, Gores G, Porayko M, Sanchez-Urdazpal L, Steers J, Krom RA. (1992). Calcitonin therapy does not prevent post-liver transplant fractures in patients with primary biliary cirrhosis and primary sclerosing cholangitis. Hepatology.
63 Healey JH, Paget SA, Williams-Russo P, Szatrowski TP, Schneider R, Spiera H, Mitnick H, Ales K, Schwartzberg P. (1996). A randomized controlled trial of salmon calcitonin to prevent bone loss in corticosteroid-treated temporal arteritis and polymyalgia rheumatica. Calcif Tissue Int.
64 Henderson K, Eisman J, Keogh A, MacDonald P, Glanville A, Spratt P, Sambrook P. (2001). Protective effect of short-tem calcitriol or cyclical etidronate on bone loss after cardiac or lung transplantation. Journal of Bone and Mineral Research : the Official Journal of the American Society for Bone and Mineral Research.
65 Herd RJ, Balena R, Blake GM, Ryan PJ, Fogelman I. (1997). The prevention of early postmenopausal bone loss by cyclical etidronate therapy: a 2-year, double-blind, placebo-controlled study. Am J Med.
66 Hizmetli S, Elden H, Kaptanoglu E, Nacitarhan V, Kocagil S. (1998). The effect of different doses of calcitonin on bone mineral density and fracture risk in postmenopausal osteoporosis. Int J Clin Pract.
67 Hosking D, Chilvers CE, Christiansen C, Ravn P, Wasnich R, Ross P, McClung M, Balske A, Thompson D, Daley M, Yates AJ. (1998). Prevention of bone loss with alendronate in postmenopausal women under 60 years of age. Early Postmenopausal Intervention Cohort Study Group. N Engl J Med.
68 Hulley S, Furberg C, Barrett-Connor E, Cauley J, Grady D, Haskell W, Knopp R, Lowery M, Satterfield S, Schrott H, Vittinghoff E, Hunninghake D. (2002). Noncardiovascular disease outcomes during 6.8 years of hormone therapy: Heart and Estrogen/progestin Replacement Study follow-up (HERS II). JAMA.
69 Hulley S, Grady D, Bush T, Furberg C, Herrington D, Riggs B, Vittinghoff E. (1998). Randomized trial of estrogen plus progestin for secondary prevention of coronary heart disease in postmenopausal women. Heart and Estrogen/progestin Replacement Study (HERS) Research Group. JAMA.
70 Iwamoto J, Takeda T, Sato Y, Uzawa M. (2004). Effects of alendronate on metacarpal and lumbar bone mineral density, bone resorption, and chronic back pain in postmenopausal women with osteoporosis. Clin Rheumatol.
71 Iwamoto J, Takeda T, Ichimura S. (2001). Effect of menatetrenone on bone mineral density and incidence of vertebral fractures in postmenopausal women with osteoporosis: a comparison with the effect of etidronate. Journal of Orthopaedic Science : Official Journal of the Japanese Orthopaedic Association.
72 Jenkins EA, Walker-Bone KE, Wood A, McCrae FC, Cooper C, Cawley MI. (1999). The prevention of corticosteroid-induced bone loss with intermittent cyclical etidronate. Scandinavian Journal of Rheumatology.
73 Jinnouchi Y. (2000). Efficacy of intermittent etidronate therapy for corticosteroid-induced osteoporosis in patients with diffuse connective tissue disease. Kurume Med J.
74 Johnell O, Cauley JA, Kulkarni PM, Wong M, Stock JL. (2004). Raloxifene reduces risk of vertebral fractures. J Fam Pract.
75 Johnell O, Cauley JA, Kulkarni PM, Wong M, Stock JL. (2004). Raloxifene reduces risk of vertebral fractures and breast cancer in postmenopausal women regardless of prior hormone therapy. The Journal of Family Practice.
76 Johnell O, Kanis JA, Black DM, Balogh A, Poor G, Sarkar S, Zhou C, Pavo I. (2004). Associations between baseline risk factors and vertebral fracture risk in the Multiple Outcomes of Raloxifene Evaluation (MORE) Study. Journal of Bone and Mineral Research : the Official Journal of the American Society for Bone and Mineral Research.
77 Kanis JA, Johnell O, Black DM, Downs RW, Sarkar S, Fuerst T, Secrest RJ, Pavo I. (2003). Effect of raloxifene on the risk of new vertebral fracture in postmenopausal women with osteopenia or osteoporosis: a reanalysis of the Multiple Outcomes of Raloxifene Evaluation trial. Bone.
78 Keegan TH, Schwartz AV, Bauer DC, Sellmeyer DE, Kelsey JL. (2004). Effect of alendronate on bone mineral density and biochemical markers of bone turnover in type 2 diabetic women: the fracture intervention trial. Diabetes Care.
79 Khan AA, Bilezikian JP, Kung AW, Ahmed MM, Dubois SJ, Ho AY, Schussheim D, Rubin MR, Shaikh AM, Silverberg SJ, Standish TI, Syed Z, Syed ZA. (2004). Alendronate in primary hyperparathyroidism: a double-blind, randomized, placebo-controlled trial. The Journal of Clinical Endocrinology and Metabolism.
80 Komulainen MH, Kroger H, Tuppurainen MT, Heikkinen AM, Alhava E, Honkanen R, Saarikoski S. (1998). HRT and Vit D in prevention of non-vertebral fractures in postmenopausal women; a 5 year randomized trial. Maturitas.
81 Kurland ES, Cosman F, McMahon DJ, Rosen CJ, Lindsay R, Bilezikian JP. (2000). Parathyroid hormone as a therapy for idiopathic osteoporosis in men: effects on bone mineral density and bone markers. J Clin Endocrinol Metab.
82 Kushida K, Fukunaga M, Kishimoto H, Shiraki M, Itabashi A, Inoue T, Kaneda K, Morii H, Nawata H, Yamamoto K, Ohashi Y, Orimo H. (2002). The efficacy of alendronate in reducing the risk for vertebral fracture in Japanese patients with osteoporosis: A randomized, double-blind, active-controlled, double-dummy trial. Current Therapeutic Research, Clinical & Experimental.
83 Kushida K, Shiraki M, Nakamura T, Kishimoto H, Morii H, Yamamoto K, Kaneda K, Fukunaga M, Inoue T, Nakashima M, Orimo H. (2004). Alendronate reduced vertebral fracture risk in postmenopausal Japanese women with osteoporosis: a 3-year follow-up study. Journal of Bone and Mineral Metabolism.
84 Lane NE, Sanchez S, Modin GW, Genant HK, Pierini E, Arnaud CD. (2000). Bone mass continues to increase at the hip after parathyroid hormone treatment is discontinued in glucocorticoid-induced osteoporosis: results of a randomized controlled clinical trial. Journal of Bone and Mineral Research : the Official Journal of the American Society for Bone and Mineral Research.
85 Lane NE, Sanchez S, Modin GW, Genant HK, Pierini E, Arnaud CD. (1998). Parathyroid hormone treatment can reverse corticosteroid-induced osteoporosis. Results of a randomized controlled clinical trial. J Clin Invest.
86 Laroche, M.; Andrieu, V.; Constantin, A., and Mazieres, B. Beneficial effect on bone density in male osteoporosis of postmenopausal osteoporosis treatment (fluoride, etidronate, and calcitriol). Clin Exp Rheumatol. 1998 Nov–1998 Dec 31; 16(6):760. Rec #: 1491
87 Lems WF, Jacobs JW, Bijlsma JW, van Veen GJ, Houben HH, Haanen HC, Gerrits MI, van Rijn HJ. (1997). Is addition of sodium fluoride to cyclical etidronate beneficial in the treatment of corticosteroid induced osteoporosis?. Ann Rheum Dis.
88 Levis S, Quandt SA, Thompson D, Scott J, Schneider DL, Ross PD, Black D, Suryawanshi S, Hochberg M, Yates J. (2002). Alendronate reduces the risk of multiple symptomatic fractures: results from the fracture intervention trial. J Am Geriatr Soc.
89 Lindor KD, Jorgensen RA, Tiegs RD, Khosla S, Dickson ER. (2000). Etidronate for osteoporosis in primary biliary cirrhosis: a randomized trial. Journal of Hepatology.
90 Liu JL, Zhu HM, Huang QR, Zhang ZL, Li HL, Qin YJ, Zhang Y, Wei DL, Lu JH, Liu H, Chen XP, Liu YJ, Ekangaki A, Zheng YM, Diez-Perez A, Harper K. (2004). Effects of raloxifene hydrochloride on bone mineral density, bone metabolism and serum lipids in Chinese postmenopausal women with osteoporosis: a multi-center, randomized, placebo-controlled clinical trial. Chin Med J (Engl).
91 Liu JL, Zhu HM, Huang QR, Zhang ZL, Li HL, Qin YJ, Zhang Y, Wei DL, Lu JH, Liu H, Chen XP, Liu YJ, Ekangaki A, Zheng YM, Diez-Perez A, Harpe K. (2004). [Effect of raloxifene hydrochloride on bone mineral density, bone metabolism and serum lipids in Chinese postmenopausal women with osteoporosis]. Zhonghua Yi Xue Za Zhi.
92 Luckey MM, Gilchrist N, Bone HG, Davie MW, de Villiers TJ, Wu M, Daifotis AG, Santora AC, Orloff JJ. (2003). Therapeutic equivalence of alendronate 35 milligrams once weekly and 5 milligrams daily in the prevention of postmenopausal osteoporosis. Obstet Gynecol.
93 Luengo M, Pons F, Martinez de Osaba MJ, Picado C. (1994). Prevention of further bone mass loss by nasal calcitonin in patients on long term glucocorticoid therapy for asthma: a two year follow up study. Thorax.
94 Lufkin EG, Wahner HW, O'Fallon WM, Hodgson SF, Kotowicz MA, Lane AW, Judd HL, Caplan RH, Riggs BL. (1992). Treatment of postmenopausal osteoporosis with transdermal estrogen. Ann Intern Med.
95 Lufkin EG, Whitaker MD, Nickelsen T, Argueta R, Caplan RH, Knickerbocker RK, Riggs BL. (1998). Treatment of established postmenopausal osteoporosis with raloxifene: a randomized trial. J Bone Miner Res.
96 Lyritis GP, Tsakalakos N, Paspati I, Skarantavos G, Galanos A, Androulakis C. (1997). The effect of a modified etidronate cyclical regimen on postmenopausal osteoporosis: a four-year study. Clin Rheumatol.
97 Maricic M, Adachi J, Meunier P, Lufkin E, Delmas P, Draper M. (1998). Raloxifene 60 mg/day has effects within 12 motnhs in postmenopausal osteoporosis treatment and prevention studies [abstract]. Arthritis Rheum.
98 Maricic M, Adachi JD, Sarkar S, Wu W, Wong M, Harper KD. (2002). Early effects of raloxifene on clinical vertebral fractures at 12 months in postmenopausal women with osteoporosis. Arch Intern Med.
99 McClung MR, Geusens P, Miller PD, Zippel H, Bensen WG, Roux C, Adami S, Fogelman I, Diamond T, Eastell R, Meunier PJ, Reginster JY. (2001). Effect of risedronate on the risk of hip fracture in elderly women. Hip Intervention Program Study Group. N Engl J Med.
100 McClung MR, Wasnich RD, Hosking DJ, Christiansen C, Ravn P, Wu M, Mantz AM, Yates J, Ross PD, Santora AC. (2004). Prevention of postmenopausal bone loss: six-year results from the Early Postmenopausal Intervention Cohort Study. J Clin Endocrinol Metab.
101 Mellstrom DD, Sorensen OH, Goemaere S, Roux C, Johnson TD, Chines AA. (2004). Seven years of treatment with risedronate in women with postmenopausal osteoporosis. Calcif Tissue Int.
102 Meunier PJ, Confavreux E, Tupinon I, Hardouin C, Delmas PD, Balena R. (1997). Prevention of early postmenopausal bone loss with cyclical etidronate therapy (a double-blind, placebo-controlled study and 1-year follow-up). J Clin Endocrinol Metab.
103 Meyer HE, Smedshaug GB, Kvaavik E, Falch JA, Tverdal A, Pedersen JI. (2002). Can vitamin D supplementation reduce the risk of fracture in the elderly? A randomized controlled trial. J Bone Miner Res.
104 Michalska D, Stepan JJ, Basson BR, Pavo I. (2006). The effect of raloxifene after discontinuation of long-term alendronate treatment of postmenopausal osteoporosis. J Clin Endocrinol Metab.
105 Miller P, Roux C, McClung M. (1999). Risedronate reduces hip fractures in patients with low femoral neck bone mineral density. Arthritis and Rheumatism.
106 Miller PD, Watts NB, Licata AA, Harris ST, Genant HK, Wasnich RD, Ross PD, Jackson RD, Hoseyni MS, Schoenfeld SL, Valent DJ, Chesnut CH. (1997). Cyclical etidronate in the treatment of postmenopausal osteoporosis: efficacy and safety after seven years of treatment. Am J Med.
107 Montessori ML, Scheele WH, Netelenbos JC, Kerkhoff JF, Bakker K. (1997). The use of etidronate and calcium versus calcium alone in the treatment of postmenopausal osteopenia: results of three years of treatment. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
108 Morii H, Ohashi Y, Taketani Y, Fukunaga M, Nakamura T, Itabashi A, Sarkar S, Harper K. (2003). Effect of raloxifene on bone mineral density and biochemical markers of bone turnover in Japanese postmenopausal women with osteoporosis: results from a randomized placebo-controlled trial. Osteoporos Int.
109 Mortensen L, Charles P, Bekker PJ, Digennaro J, Johnston CC. (1998). Risedronate increases bone mass in an early postmenopausal population: two years of treatment plus one year of follow-up. J Clin Endocrinol Metab.
110 Mosekilde L, Beck-Nielsen H, Sorensen OH, Nielsen SP, Charles P, Vestergaard P, Hermann AP, Gram J, Hansen TB, Abrahamsen B, Ebbesen EN, Stilgren L, Jensen LB, Brot C, Hansen B, Tofteng CL, Eiken P, Kolthoff N. (2000). Hormonal replacement therapy reduces forearm fracture incidence in recent postmenopausal women - results of the Danish Osteoporosis Prevention Study. Maturitas.
111 Murphy MG, Weiss S, McClung M, Schnitzer T, Cerchio K, Connor J, Krupa D, Gertz BJ. (2001). Effect of alendronate and MK-677 (a growth hormone secretagogue), individually and in combination, on markers of bone turnover and bone mineral density in postmenopausal osteoporotic women. The Journal of Clinical Endocrinology and Metabolism.
112 Neer RM, Arnaud CD, Zanchetta JR, Prince R, Gaich GA, Reginster JY, Hodsman AB, Eriksen EF, Ish-Shalom S, Genant HK, Wang O, Mitlak BH. (2001). Effect of parathyroid hormone (1–34) on fractures and bone mineral density in postmenopausal women with osteoporosis. N Engl J Med.
113 Nevitt MC, Ross PD, Palermo L, Musliner T, Genant HK, Thompson DE. (1999). Association of prevalent vertebral fractures, bone density, and alendronate treatment with incident vertebral fractures: effect of number and spinal location of fractures. The Fracture Intervention Trial Research Group. Bone.
114 Nevitt MC, Thompson DE, Black DM, Rubin SR, Ensrud K, Yates AJ, Cummings SR. (2000). Effect of alendronate on limited-activity days and bed-disability days caused by back pain in postmenopausal women with existing vertebral fractures. Fracture Intervention Trial Research Group. Arch Intern Med.
115 Orwoll E, Ettinger M, Weiss S, Miller P, Kendler D, Graham J, Adami S, Weber K, Lorenc R, Pietschmann P, Vandormael K, Lombardi A. (2000). Alendronate for the treatment of osteoporosis in men. N Engl J Med.
116 Overgaard K, Christiansen C. (1996). A new biochemical marker of bone resorption for follow-up on treatment with nasal salmon calcitonin. Calcified Tissue International.
117 Overgaard K, Hansen MA, Jensen SB, Christiansen C. (1992). Effect of salcatonin given intranasally on bone mass and fracture rates in established osteoporosis: a dose-response study. BMJ.
118 Peichl P, Rintelen B, Kumpan W, Broll H. (1999). Increase of axial and appendicular trabecular and cortical bone density in established osteoporosis with intermittent nasal salmon calcitonin therapy. Gynecological Endocrinology : the Official Journal of the International Society of Gynecological Endocrinology.
119 Pitt P, Li F, Todd P, Webber D, Pack S, Moniz C. (1998). A double blind placebo controlled study to determine the effects of intermittent cyclical etidronate on bone mineral density in patients on long-term oral corticosteroid treatment. Thorax.
120 Pols HA, Felsenberg D, Hanley DA, Stepan J, Munoz-Torres M, Wilkin TJ, Qin-sheng G, Galich AM, Vandormael K, Yates AJ, Stych B. (1999). Multinational, placebo-controlled, randomized trial of the effects of alendronate on bone density and fracture risk in postmenopausal women with low bone mass: results of the FOSIT study. Foxamax International Trial Study Group. Osteoporos Int.
121 Recker RR, Davies KM, Dowd RM, Heaney RP. (1999). The effect of low-dose continuous estrogen and progesterone therapy with calcium and vitamin D on bone in elderly women. A randomized, controlled trial. Ann Intern Med.
122 Reginster J, Minne H, Sorensen OH. (2000). Randomized trial of the effects of risedronate on vetebral fractures in women with established postmenopausal osteoporosis. Osteoposos Int.
123 Reginster JY, Felsenberg D, Pavo I, Stepan J, Payer J, Resch H, Gluer CC, Muhlenbacher D, Quail D, Schmitt H, Nickelsen T. (2003). Effect of raloxifene combined with monofluorophosphate as compared with monofluorophosphate alone in postmenopausal women with low bone mass: a randomized, controlled trial. Osteoporos Int.
124 Reginster JY, Sarkar S, Zegels B, Henrotin Y, Bruyere O, Agnusdei D, Collette J. (2004). Reduction in PINP, a marker of bone metabolism, with raloxifene treatment and its relationship with vertebral fracture risk. Bone.
125 Reid DM, Hughes RA, Laan RF, Sacco-Gibson NA, Wenderoth DH, Adami S, Eusebio RA, Devogelaer JP. (2000). Efficacy and safety of daily risedronate in the treatment of corticosteroid-induced osteoporosis in men and women: a randomized trial. European Corticosteroid-Induced Osteoporosis Treatment Study. J Bone Miner Res.
126 Rico H, Hernandez ER, Revilla M, Gomez-Castresana F. (1992). Salmon calcitonin reduces vertebral fracture rate in postmenopausal crush fracture syndrome. Bone Miner.
127 Rico H, Revilla M, Hernandez ER, Villa LF, Alvarez de Buergo M. (1995). Total and regional bone mineral content and fracture rate in postmenopausal osteoporosis treated with salmon calcitonin: a prospective study. Calcif Tissue Int.
128 Ringe, J. D.; Coser, A., and Dorst, A. Alendronate treatment of established primary osteoporosis in men: two-year results of a prospective comparative two-arm study. in press. Rec #: 3107
129 Ringe JD, Faber H, Dorst A. (2001). Alendronate treatment of established primary osteoporosis in men: results of a 2-year prospective study. The Journal of Clinical Endocrinology and Metabolism.
130 Rizzoli R, Greenspan SL, Bone G, Schnitzer TJ, Watts NB, Adami S, Foldes AJ, Roux C, Levine MA, Uebelhart B, Santora AC, Kaur A, Peverly CA, Orloff JJ. (2002). Two-year results of once-weekly administration of alendronate 70 mg for the treatment of postmenopausal osteoporosis. J Bone Miner Res.
131 Ross PD, Genant HK, Davis JW, Miller PD, Wasnich RD. (1993). Predicting vertebral fracture incidence from prevalent fractures and bone density among non-black, osteoporotic women. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
132 Rossini M, Gatti D, Girardello S, Braga V, James G, Adami S. (2000). Effects of two intermittent alendronate regimens in the prevention or treatment of postmenopausal osteoporosis. Bone.
133 Rossini M, Gatti D, Isaia G, Sartori L, Braga V, Adami S. (2001). Effects of oral alendronate in elderly patients with osteoporosis and mild primary hyperparathyroidism. J Bone Miner Res.
134 Rossouw JE, Anderson GL, Prentice RL, LaCroix AZ, Kooperberg C, Stefanick ML, Jackson RD, Beresford SA, Howard BV, Johnson KC, Kotchen JM, Ockene J. (2002). Risks and benefits of estrogen plus progestin in healthy postmenopausal women: principal results From the Women's Health Initiative randomized controlled trial. JAMA.
135 Roux C, Oriente P, Laan R, Hughes RA, Ittner J, Goemaere S, Di Munno O, Pouilles JM, Horlait S, Cortet B. (1998). Randomized trial of effect of cyclical etidronate in the prevention of corticosteroid-induced bone loss. Ciblos Study Group. J Clin Endocrinol Metab.
136 Saag KG, Emkey R, Schnitzer TJ, Brown JP, Hawkins F, Goemaere S, Thamsborg G, Liberman UA, Delmas PD, Malice MP, Czachur M, Daifotis AG. (1998). Alendronate for the prevention and treatment of glucocorticoid-induced osteoporosis. Glucocorticoid-Induced Osteoporosis Intervention Study Group. N Engl J Med.
137 Sambrook P, Birmingham J, Kelly P, Kempler S, Nguyen T, Pocock N, Eisman J. (1993). Prevention of corticosteroid osteoporosis. A comparison of calcium, calcitriol, and calcitonin. N Engl J Med.
138 Sambrook PN, Kotowicz M, Nash P, Styles CB, Naganathan V, Henderson-Briffa KN, Eisman JA, Nicholson GC. (2003). Prevention and treatment of glucocorticoid-induced osteoporosis: a comparison of calcitriol, vitamin D plus calcium, and alendronate plus calcium. J Bone Miner Res.
139 Sambrook PN, Rodriguez JP, Wasnich RD, Luckey MM, Kaur A, Meng L, Lombardi A. (2004). Alendronate in the prevention of osteoporosis: 7-year follow-up. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
140 Sarkar S, Mitlak BH, Wong M, Stock JL, Black DM, Harper KD. (2002). Relationships between bone mineral density and incident vertebral fracture risk with raloxifene therapy. J Bone Miner Res.
141 Sarkar S, Reginster JY, Crans GG, Diez-Perez A, Pinette KV, Delmas PD. (2004). Relationship between changes in biochemical markers of bone turnover and BMD to predict vertebral fracture risk. Journal of Bone and Mineral Research : the Official Journal of the American Society for Bone and Mineral Research.
142 Sato Y, Asoh T, Kaji M, Oizumi K. (2000). Beneficial effect of intermittent cyclical etidronate therapy in hemiplegic patients following an acute stroke. Journal of Bone and Mineral Research : the Official Journal of the American Society for Bone and Mineral Research.
143 Seeman, E. The antifracture efficacy of alendronate. 1999. Rec #: 1839
144 Shane E, Addesso V, Namerow PB, McMahon DJ, Lo SH, Staron RB, Zucker M, Pardi S, Maybaum S, Mancini D. (2004). Alendronate versus calcitriol for the prevention of bone loss after cardiac transplantation. N Engl J Med.
145 Shimon I, Eshed V, Doolman R, Sela BA, Karasik A, Vered I. (2005). Alendronate for osteoporosis in men with androgen-repleted hypogonadism. Osteoporos Int.
146 Shiota E. (1998). Evaluation of the drug therapy for established osteoporosis by dual-energy x-ray absorptiometry. Fukuoka Igaku Zasshi = Hukuoka Acta Medica.
147 Shiota E, Tsuchiya K, Yamaoka K, Kawano O. (2001). Effect of intermittent cyclical treatment with etidronate disodium (HEBP) and calcium plus alphacalcidol in postmenopausal osteoporosis. Journal of Orthopaedic Science : Official Journal of the Japanese Orthopaedic Association.
148 Silverman SL, Chesnut C, Andriano K. (1998). Salmon calcitonin nasal spray (NS-CT) reduces risk of vertebral fractures(s) (VF) in established osteoporosis and has continuous efficacy with prolonged treatment: accrued 5 year worldwide data of the PROOF study. Bone.
149 Silverman SL, Minshall ME, Shen W, Harper KD, Xie S. (2001). The relationship of health-related quality of life to prevalent and incident vertebral fractures in postmenopausal women with osteoporosis: results from the Multiple Outcomes of Raloxifene Evaluation Study. Arthritis Rheum.
150 Siris E, Adachi JD, Lu Y, Fuerst T, Crans GG, Wong M, Harper KD, Genant HK. (2002). Effects of raloxifene on fracture severity in postmenopausal women with osteoporosis: results from the MORE study. Multiple Outcomes of Raloxifene Evaluation. Osteoporos Int.
151 Skingle SJ, Moore DJ, Crisp AJ. (1997). Cyclical etidronate increases lumbar spine bone density in patients on long-term glucocorticosteroid therapy. Int J Clin Pract.
152 Stefanick ML, Cochrane BB, Hsia J, Barad DH, Liu JH, Johnson SR. (2003). The Women's Health Initiative postmenopausal hormone trials: overview and baseline characteristics of participants. Ann Epidemiol.
153 Stock JL, Avioli LV, Baylink DJ. (1997). Calcitonin-salmon nasal spray reduces the incidence of new vertebral fractures in post-menopausal women: three-year interim results of the PROOF study. J Bone Miner Res.
154 Storm T, Kollerup G, Thamsborg G, Genant HK, Sorensen OH. (1996). Five years of clinical experience with intermittent cyclical etidronate for postmenopausal osteoporosis. J Rheumatol.
155 Storm T, Thamsborg G, Steiniche T, Genant HK, Sorensen OH. (1990). Effect of intermittent cyclical etidronate therapy on bone mass and fracture rate in women with postmenopausal osteoporosis. N Engl J Med.
156 Szucs J, Horvath C, Kollin E, Szathmari M, Hollo I. (1992). Three-year calcitonin combination therapy for postmenopausal osteoporosis with crush fractures of the spine. Calcif Tissue Int.
157 Tonino RP, Meunier PJ, Emkey R, Rodriguez-Portales JA, Menkes CJ, Wasnich RD, Bone HG, Santora AC, Wu M, Desai R, Ross PD. (2000). Skeletal benefits of alendronate: 7-year treatment of postmenopausal osteoporotic women. Phase III Osteoporosis Treatment Study Group. J Clin Endocrinol Metab.
158 Ugur A, Guvener N, Isiklar I, Karakayali H, Erdal R. (2000). Efficiency of preventive treatment for osteoporosis after renal transplantation. Transplantation Proceedings.
159 Valimaki MJ, Kinnunen K, Volin L, Tahtela R, Loyttyniemi E, Laitinen K, Makela P, Keto P, Ruutu T. (1999). A prospective study of bone loss and turnover after allogeneic bone marrow transplantation: effect of calcium supplementation with or without calcitonin. Bone Marrow Transplant.
160 Valimaki MJ, Kinnunen K, Tahtela R, Loyttyniemi E, Laitinen K, Makela P, Keto P, Nieminen M. (1999). A prospective study of bone loss and turnover after cardiac transplantation: effect of calcium supplementation with or without calcitonin. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
161 Van Cleemput J, Daenen W, Geusens P, Dequeker P, Van De Werf F, VanHaecke J. (1996). Prevention of bone loss in cardiac transplant recipients. A comparison of biphosphonates and vitamin D. Transplantation.
162 van der Poest Clement E, Patka P, Vandormael K, Haarman H, Lips P. (2000). The effect of alendronate on bone mass after distal forearm fracture. Journal of Bone and Mineral Research : the Official Journal of the American Society for Bone and Mineral Research.
163 Watts NB, Harris ST, Genant HK, Wasnich RD, Miller PD, Jackson RD, Licata AA, Ross P, Woodson GC, Yanover MJ, et al. (1990). Intermittent cyclical etidronate treatment of postmenopausal osteoporosis. N Engl J Med.
164 Wolfhagen FH, van Buuren HR, den Ouden JW, Hop WC, van Leeuwen JP, Schalm SW, Pols HA. (1997). Cyclical etidronate in the prevention of bone loss in corticosteroid-treated primary biliary cirrhosis. A prospective, controlled pilot study. J Hepatol.
165 Worth H, Stammen D, Keck E. (1994). Therapy of steroid-induced bone loss in adult asthmatics with calcium, vitamin D, and a diphosphonate. Am J Respir Crit Care Med.
166 Zegels B, Eastell R, Russell RG, Ethgen D, Roumagnac I, Collette J, Reginster JY. (2001). Effect of high doses of oral risedronate (20 mg/day) on serum parathyroid hormone levels and urinary collagen cross-link excretion in postmenopausal women with spinal osteoporosis. Bone.

## REJECTED: Population not human

1 Arjmandi BH, Birnbaum RS, Juma S, Barengolts E, Kukreja SC. (2000). The synthetic phytoestrogen, ipriflavone, and estrogen prevent bone loss by different mechanisms. Calcif Tissue Int.
2 Bowman AR, Sass DA, Dissanayake IR, Ma YF, Liang H, Yuan Z, Jee WS, Epstein S. (1997). The role of testosterone in cyclosporine-induced osteopenia. J Bone Miner Res.
3 Canalis E, McCarthy T, Centrella M. (1988). Growth factors and the regulation of bone remodeling. J Clin Invest.
4 de Vries E, van der Weij JP, van der Veen CJ, van Paassen HC, Jager MJ, Sleeboom HP, Bijvoet OL, Cats A. (1982). In vitro effect of (3-amino-1-hydroxypropylidene)-1,1-bisphosphonic acid (APD) on the function of mononuclear phagocytes in lymphocyte proliferation. Immunology.
5 Delmas PD, Vergnaud P, Arlot ME, Pastoureau P, Meunier PJ, Nilssen MH. (1995). The anabolic effect of human PTH (1–34) on bone formation is blunted when bone resorption is inhibited by the bisphosphonate tiludronate—is activated resorption a prerequisite for the in vivo effect of PTH on formation in a remodeling system?. Bone.
6 Devogelaer JP. (1998). A risk-benefit assessment of alendronate in the treatment of involutional osteoporosis. Drug Saf.
7 Fleiss JL. (1993). The statistical basis of meta-analysis. Stat Methods Med Res.
8 Hayes WC, Shea M, Rodan GA. (1999). Preclinical evidence of normal bone with alendronate. Int J Clin Pract Suppl.
9 Haynes, R. B.; Wilczynski, N.; McKibbon, K. A.; Walker, C. J., and Sinclair, J. C. Developing optimal search strategies for detecting clinically sound studies in MEDLINE. J Am Med Inform Assoc. 1994 Nov–1994 Dec 31; 1(6):447–58. Rec #: 2907
10 Herrak P, Gortz B, Hayer S, Redlich K, Reiter E, Gasser J, Bergmeister H, Kollias G, Smolen JS, Schett G. (2004). Zoledronic acid protects against local and systemic bone loss in tumor necrosis factor-mediated arthritis. Arthritis Rheum.
11 Jilka RL, Weinstein RS, Bellido T, Roberson P, Parfitt AM, Manolagas SC. (1999). Increased bone formation by prevention of osteoblast apoptosis with parathyroid hormone. J Clin Invest.
12 Kimmel DB, Bozzato RP, Kronis KA, Coble T, Sindrey D, Kwong P, Recker RR. (1993). The effect of recombinant human (1–84) or synthetic human (1–34) parathyroid hormone on the skeleton of adult osteopenic ovariectomized rats. Endocrinology.
13 Kroll MH. (2000). Parathyroid hormone temporal effects on bone formation and resorption. Bull Math Biol.
14 Lacy ME, Bevan JA, Boyce RW, Geddes AD. (1994). Antiresorptive drugs and trabecular bone turnover: validation and testing of a computer model. Calcified Tissue International.
15 Lane NE, Thompson JM, Strewler GJ, Kinney JH. (1995). Intermittent treatment with human parathyroid hormone (hPTH[1–34]) increased trabecular bone volume but not connectivity in osteopenic rats. J Bone Miner Res.
16 Li J, Mashiba T, Burr DB. (2001). Bisphosphonate treatment suppresses not only stochastic remodeling but also the targeted repair of microdamage. Calcif Tissue Int.
17 Lotinun S, Sibonga JD, Turner RT. (2002). Differential effects of intermittent and continuous administration of parathyroid hormone on bone histomorphometry and gene expression. Endocrine.
18 Manolagas SC, Weinstein RS, Jilka RL, Parfitt AM. (1998). Parathyroid hormone and corticosteroid-induced osteoporosis. Lancet.
19 Martin TJ, Suva LJ. (1988). Parathyroid hormone-related protein: a novel gene product. Baillieres Clin Endocrinol Metab.
20 Morony S, Capparelli C, Lee R, Shimamoto G, Boone T, Lacey DL, Dunstan CR. (1999). A chimeric form of osteoprotegerin inhibits hypercalcemia and bone resorption induced by IL-1beta, TNF-alpha, PTH, PTHrP, and 1, 25(OH)2D3. J Bone Miner Res.
21 Naylor AF. (1967). Small sample considerations in combining 2 X 2 tables. Biometrics.
22 Nishida, S.; Yamaguchi, A.; Tanizawa, T.; Endo, N.; Mashiba, T.; Uchiyama, Y.; Suda, T.; Yoshiki, S., and Takahashi, H. E. Increased bone formation by intermittent parathyroid hormone administration is due to the stimulation of proliferation and differentiation of osteoprogenitor cells in bone marrow. Bone. 1994 Nov–1994 Dec 31; 15(6):717–23. Rec #: 2344
23 Pellegrini M, Bisello A, Rosenblatt M, Chorev M, Mierke DF. (1997). Conformational studies of RS-66271, an analog of parathyroid hormone-related protein with pronounced bone anabolic activity. J Med Chem.
24 Peter C, Rodan GA. (1999). Preclinical safety profile of alendronate. Int J Clin Pract Suppl.
25 Sato M, Zeng GQ, Rowley E, Turner CH. (1998). LY353381 × HCl: an improved benzothiophene analog with bone efficacy complementary to parathyroid hormone-(1–34). Endocrinology.
26 Skripitz R, Aspenberg P. (2004). Parathyroid hormone—a drug for orthopedic surgery?. Acta Orthop Scand.
27 Tam CS, Heersche JN, Murray TM, Parsons JA. (1982). Parathyroid hormone stimulates the bone apposition rate independently of its resorptive action: differential effects of intermittent and continuous administration. Endocrinology.
28 Tamaki H, Akamine T, Goshi N, Kurata H, Sakou T. (1998). Effects of exercise training and etidronate treatment on bone mineral density and trabecular bone in ovariectomized rats. Bone.
29 Yanase T, Suzuki S, Goto K, Nomura M, Okabe T, Takayanagi R, Nawata H. (2003). Aromatase in bone: roles of Vitamin D3 and androgens. J Steroid Biochem Mol Biol.

## REJECTED: Duplicate article

1 Aris RM, Lester GE, Caminiti M, Blackwood AD, Hensler M, Lark RK, Hecker TM, Renner JB, Guillen U, Brown SA, Neuringer IP, Chalermskulrat W, Ontjes DA. (2004). Efficacy of alendronate in adults with cystic fibrosis with low bone density. American Journal of Respiratory and Critical Care Medicine.
2 Aris, R. M.; Lester, G. E.; Neuringer, I. P.; Winders, A. W.; Gott, K. K.; Rea, J., and et al. Efficacy of pamidronate for osteoporosis in cyctic fibrosis patients following lung transplantation [abstract]. 1998(Suppl 17): 365_. Rec #: 3001
3 Body JJ, Gaich GA, Scheele WH. (2002). A randomised double-blind trial to compare the efficacy of teriparatide with alendronate in postmenopausal women with osteoporosis. J Clin Endocrinol Metab.
4 Bone HG, Hosking D, Devogelaer JP, Tucci JR, Emkey RD, Tonino RP, Rodriguez-Portales JA, Downs RW, Gupta J, Santora AC, et al. (2004). Alendronate phase III osteoporosis treatment study Group. 10 years' experience with alendronate for osteoporosis in postmenopausal women. N Engl J Med.
5 Cosman F. (2001). Parathyroid hormone added to established hormone therapy: effects on vertebral fracture and maintenance of bone mass after parathyroid hormone withdrawal. J Bone Miner Res.
6 Fuleihan Gel H, Salamoun M, Mourad YA, Chehal A, Salem Z, Mahfoud Z, Shamseddine A. (2005). Pamidronate in the prevention of chemotherapy-induced bone loss in premenopausal women with breast cancer: a randomized controlled trial. J Clin Endocrinol Metab.
7 Herd RJ, Balena R, Blake GM, Ryan PJ, Fogelman I. (1997). The prevention of early postmenopausal bone loss by cyclical etidronate therapy: a 2-year, double-blind, placebo-controlled study. Am J of Medicine.
8 Koc, M.; Tuglular, S.; Arikan, H.; Ozener, C., and Akoglu, E. Alendronate increases bone mineral density in renal transplant recipients. XXXVIII Congress of the European Renal Association European Dialysis & Transplant Association; Vienna, Austria. Rec #: 3065
9 Licata AA. (1990). Diphosphonates in the treatment of osteoporosis. Cleve Clin J Med.
10 McClung MR, Geusen P, Miller PD, Zippel H, Bensen WG, Roux C. (2001). Effect of risedronate on the risk of hip fracture in elderly women. Hip intervention program study group. N Engl J Med.
11 Meunier PJ, Vignot E, Garnero P, Confavreux E, Sarkar S, et al. (1998). Treatment of postmenopausal osteoporosis with raloxifene [abstract]. Osteoporosis Int.
12 Morabito N, Lasco A, Gaudio A, Crisafulli A, Di Pietro C, Meo A, Frisina N. (2002). Bisphosphonates in the treatment of thalassemia-induced osteoporosis. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
13 Orwoll ES, Scheele WH, Paul S, Adami S, Syversen U, Diez-Perez A, Kaufman JM, Clancy AD, Gaich GA. (2003). The effect of teriparatide. J Bone Miner Res.
14 Pols HA. (1997). A multinational, placebo-controlled study of alendronate in post menopausal women with osteoporosis—results from the FOSIT study. Bone Miner Res.
15 Reginster J, Minne HW, Sorensen OH, Hooper M, Roux C, Brandi ML, Lund B, Ethgen D, Pack S, Roumagnac I, Eastell R. (2000). Randomized trial of the effects of risedronate on vertebral fractures in women with established postmenopausal osteoporosis. Vertebral Efficacy with Risedronate Therapy (VERT) Study Group. Osteoporos Int.
16 Ringe JD, Dorst A, Faber H, Ibach K. (2004). Alendronate treatment of established primary osteoporosis in men: 3-year results of a prospective, comparative, two-arm study. Rheumatol Int.
17 Ringe JD, Faber H, Dorst A. (2001). Alendronate treatment of established primary osteoporosis in men: results of a 2-year prospective study. J Clin Endocrinol Metab.
18 Talamini R, Franceschi S, Dal Maso L, Negri E, Conti E, Filiberti R, Montella M, Nanni O, La Vecchia C. (1998). The influence of reproductive and hormonal factors on the risk of colon and rectal cancer in women. Eur J Cancer.
19 Tucci JR, Tonino RP, Emkey RD, Peverly CA, Kher U, Santora AC. (1996). Effect of three years of oral alendronate treatment in postmenopausal women with osteoporosis. Am J Med.
20 Wallach S, Cohen S, Reid DM, Hughes RA, Hosking DJ, Laan RF, Doherty SM, Maricic M, Rosen C, Brown J, Barton I, Chines AA. (2000). Effects of risedronate treatment on bone density and vertebral fracture in patients on corticosteroid therapy. Calcif Tissue Int.

## REJECTED: Not comparison of interest

1 Cosman F, Nieves J, Woelfert L, Formica C, Gordon S, Shen V, Lindsay R. (2001). Parathyroid hormone added to established hormone therapy: effects on vertebral fracture and maintenance of bone mass after parathyroid hormone withdrawal. J Bone Miner Res.
2 Cosman F, Nieves J, Zion M, Woelfert L, Luckey M, Lindsay R. (2005). Daily and cyclic parathyroid hormone in women receiving alendronate. N Engl J Med.
3 Harris ST, Eriksen EF, Davidson M, Ettinger MP, Moffett AH, Baylink DJ, Crusan CE, Chines AA. (2001). Effect of combined risedronate and hormone replacement therapies on bone mineral density in postmenopausal women. J Clin Endocrinol Metab.
4 Henderson S, Hoffman N, Prince R. (2006). A double-blind placebo-controlled study of the effects of the bisphosphonate risedronate on bone mass in patients with inflammatory bowel disease. Am J Gastroenterol.
5 Hodsman AB, Fraher LJ, Watson PH, Ostbye T, Stitt LW, Adachi JD, Taves DH, Drost D. (1997). A randomized controlled trial to compare the efficacy of cyclical parathyroid hormone versus cyclical parathyroid hormone and sequential calcitonin to improve bone mass in postmenopausal women with osteoporosis. The Journal of Clinical Endocrinology and Metabolism.
6 Iwamoto J, Takeda T, Ichimura S, Uzawa M. (2003). Early response to alendronate after treatment with etidronate in postmenopausal women with osteoporosis. Keio J Med.
7 Iwamoto J, Takeda T, Ichimura S, Matsu K, Uzawa M. (2003). Effects of cyclical etidronate with alfacalcidol on lumbar bone mineral density, bone resorption, and back pain in postmenopausal women with osteoporosis. Journal of Orthopaedic Science : Official Journal of the Japanese Orthopaedic Association.
8 Lindsay R, Cosman F, Lobo RA, Walsh BW, Harris ST, Reagan JE, Liss CL, Melton ME, Byrnes CA. (1999). Addition of alendronate to ongoing hormone replacement therapy in the treatment of osteoporosis: a randomized, controlled clinical trial. The Journal of Clinical Endocrinology and Metabolism.
9 Lindsay R, Nieves J, Formica C, Henneman E, Woelfert L, Shen V, Dempster D, Cosman F. (1997). Randomised controlled study of effect of parathyroid hormone on vertebral-bone mass and fracture incidence among postmenopausal women on oestrogen with osteoporosis. Lancet.
10 Miller, P. D.; Schwartz, E. N.; Chen, P.; Misurski, D. A., and Krege, J. H. Teriparatide in postmenopausal women with osteoporosis and mild or moderate renal impairment. Osteoporos Int. 2006 Sep 30. Rec #: 3546
11 Nuti R, Bianchi G, Brandi ML, Caudarella R, D'Erasmo E, Fiore C, Isaia GC, Luisetto G, Muratore M, Oriente P, Ortolani S. (2006). Superiority of alfacalcidol compared to vitamin D plus calcium in lumbar bone mineral density in postmenopausal osteoporosis. Rheumatol Int.
12 Reginster JY, Adami S, Lakatos P, Greenwald M, Stepan JJ, Silverman SL, Christiansen C, Rowell L, Mairon N, Bonvoisin B, Drezner MK, Emkey R, Felsenberg D, Cooper C, Delmas PD, Miller PD. (2006). Efficacy and tolerability of once-monthly oral ibandronate in postmenopausal osteoporosis: 2 year results from the MOBILE study. Ann Rheum Dis.
13 Ringe JD, Dorst A, Faber H, Schacht E, Rahlfs VW. (2004). Superiority of alfacalcidol over plain vitamin D in the treatment of glucocorticoid-induced osteoporosis. Rheumatol Int.
14 Ringe JD, Faber H, Farahmand P, Dorst A. (2006). Efficacy of risedronate in men with primary and secondary osteoporosis: results of a 1-year study. Rheumatol Int.
15 Sato Y, Kanoko T, Satoh K, Iwamoto J. (2005). Menatetrenone and vitamin D2 with calcium supplements prevent nonvertebral fracture in elderly women with Alzheimer's disease. Bone.
16 Thiebaud D, Burckhardt P, Melchior J, Eckert P, Jacquet AF, Schnyder P, Gobelet C. (1994). Two years' effectiveness of intravenous pamidronate (APD) versus oral fluoride for osteoporosis occurring in the postmenopause. Osteoporos Int.
17 Wallach S, Cohen S, Reid DM, Hughes RA, Hosking DJ, Laan RF, Doherty SM, Maricic M, Rosen C, Brown J, Barton I, Chines AA. (2000). Effects of risedronate treatment on bone density and vertebral fracture in patients on corticosteroid therapy. Calcif Tissue Int.
18 Watts NB, Josse RG, Hamdy RC, Hughes RA, Manhart MD, Barton I, Calligeros D, Felsenberg D. (2003). Risedronate prevents new vertebral fractures in postmenopausal women at high risk. J Clin Endocrinol Metab.

## REJECTED: Duplicate data

1 Aris, R. M.; Lester, G. E.; Neuringer, I. P.; Winders, A. W.; Gott, K. K.; Rea, J.; McSweeney, J.; Dupuis, R. E.; Egan, T. M., and Ontjes, D. A. Efficacy of pamidronate for osteoporosis in cystic fibrosis patients following lung transplantation. 1998. Rec #: 1437
2 Aris RM, Lester GE, Renner JB, Winders A, Denene Blackwood A, Lark RK, Ontjes DA. (2000). Efficacy of pamidronate for osteoporosis in patients with cystic fibrosis following lung transplantation. Am J Respir Crit Care Med.
3 Body J. (2001). A randomised controlled clinical trial to compare the efficacy of recombinant human parathyroid hormone (1–34) and alendronate sodium in postmenopausal wome with osteoporosis. Osteoporosis International.
4 Chesnut CH, Ettinger MP, Miller PD, Baylink DJ, Emkey R, Harris ST, Wasnich RD, Watts NB, Schimmer RC, Recker RR. (2005). Ibandronate produces significant, similar antifracture efficacy in North American and European women: new clinical findings from BONE. Curr Med Res Opin.
5 Crans GG, Silverman SL, Genant HK, Glass EV, Krege JH. (2004). Association of severe vertebral fractures with reduced quality of life: reduction in the incidence of severe vertebral fractures by teriparatide. Arthritis and Rheumatism.
6 Delmas PD, Recker RR, Chesnut CH, Skag A, Stakkestad JA, Emkey R, Gilbride J, Schimmer RC, Christiansen C. (2004). Daily and intermittent oral ibandronate normalize bone turnover and provide significant reduction in vertebral fracture risk: results from the BONE study. Osteoporos Int.
7 Diez-Peres, A.; Scheele, W. H.; Kaufman, J. M.; Clancy, A. D., and Orwoll, E. Recombinant human parathyroid hormone (1–34) decreases the risk of moderate/severe vertebral fractures in men with osteoporosis. 2002. Rec #: 1181
8 Felsenberg D, Miller P, Armbrecht G, Wilson K, Schimmer RC, Papapoulos SE. (2005). Oral ibandronate significantly reduces the risk of vertebral fractures of greater severity after 1, 2, and 3 years in postmenopausal women with osteoporosis. Bone.
9 Geusens, P.; Adami, S., and Bensen, W. Risedronate reduces risk of hip fracture in elerly women with osteoporosis. 27th European Symposium on Calcified Tissue; Tampere, Finland. 2000. Rec #: 3056
10 Jackson RD, Wactawski-Wende J, LaCroix AZ, Pettinger M, Yood RA, Watts NB, Robbins JA, Lewis CE, Beresford SA, Ko MG, Naughton MJ, Satterfield S, Bassford T. (2006). Effects of conjugated equine estrogen on risk of fractures and BMD in postmenopausal women with hysterectomy: results from the women's health initiative randomized trial. J Bone Miner Res.
11 Marcus R, Wang O, Satterwhite J, Mitlak B. (2003). The skeletal response to teriparatide is largely independent of age, initial bone mineral density, and prevalent vertebral fractures in postmenopausal women with osteoporosis. J Bone Miner Res.
12 Miller PD, McClung MR, Macovei L, Stakkestad JA, Luckey M, Bonvoisin B, Reginster JY, Recker RR, Hughes C, Lewiecki EM, Felsenberg D, Delmas PD, Kendler DL, Bolognese MA, Mairon N, Cooper C. (2005). Monthly oral ibandronate therapy in postmenopausal osteoporosis: 1-year results from the MOBILE study. J Bone Miner Res.
13 Oleksik AM, Ewing S, Shen W, van Schoor NM, Lips P. (2005). Impact of incident vertebral fractures on health related quality of life (HRQOL) in postmenopausal women with prevalent vertebral fractures. Osteoporos Int.
14 Porthouse J, C S, King C, Saxon L, Steele E, Aspray T. (2004). Randomised controlled trial of calcium and vitamin D supplementation for fracture prevention in primary care. Osteoporosis International : a Journal Established As Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
15 Qu Y, Wong M, Thiebaud D, Stock JL. (2005). The effect of raloxifene therapy on the risk of new clinical vertebral fractures at three and six months: a secondary analysis of the MORE trial. Curr Med Res Opin.
16 Ravn P, Bidstrup M, Wasnich RD, Davis JW, McClung MR, Balske A, Coupland C, Sahota O, Kaur A, Daley M, Cizza G. (1999). Alendronate and estrogen-progestin in the long-term prevention of bone loss: four-year results from the early postmenopausal intervention cohort study. A randomized, controlled trial. Annals of Internal Medicine.
17 Reid IR, Eastell R, Fogelman I, Adachi JD, Rosen A, Netelenbos C, Watts NB, Seeman E, Ciaccia AV, Draper MW. (2004). A comparison of the effects of raloxifene and conjugated equine estrogen on bone and lipids in healthy postmenopausal women. Archives of Internal Medicine.

## REJECTED: PTH 1–84

1 Black DM, Bilezikian JP, Ensrud KE, Greenspan SL, Palermo L, Hue T, Lang TF, McGowan JA, Rosen CJ. (2005). One year of alendronate after one year of parathyroid hormone (1–84) for osteoporosis. N Engl J Med.
2 Black DM, Greenspan SL, Ensrud KE. (2003). PaTH Study Invesigators: the effects of parathyroid hormone and alendronate alone or in combination in postmenopausal osteoporosis. N. Eng. J. Med.
3 Black DM, Greenspan SL, Ensrud KE, Palermo L, McGowan JA, Lang TF, Garnero P, Bouxsein ML, Bilezikian JP, Rosen CJ. (2003). The effects of parathyroid hormone and alendronate alone or in combination in postmenopausal osteoporosis. N Engl J Med.
4 Hodsman AB, Hanley DA, Ettinger MP, Bolognese MA, Fox J, Metcalfe AJ, Lindsay R. (2003). Efficacy and safety of human parathyroid hormone-(1–84) in increasing bone mineral density in postmenopausal osteoporosis. J Clin Endocrinol Metab.
5 Lindsay, R.; Hodsman, A., and Genant, H. A randomized controlled multi-center study of 1–84 hPTH for treatment of postmenopausal osteoporosis. 1993; 23(175, No. 5). Rec #: 3153
6 Rittmaster RS, Bolognese M, Ettinger MP, Hanley DA, Hodsman AB, Kendler DL, Rosen CJ. (2000). Enhancement of bone mass in osteoporotic women with parathyroid hormone followed by alendronate. J Clin Endocrinol Metab.
7 Schwietert HR, Groen EW, Sollie FA, Jonkman JH. (1997). Single-dose subcutaneous administration of recombinant human parathyroid hormone rhPTH(1–84) in healthy postmenopausal volunteers. Clinical Pharmacology and Therapeutics.

## REJECTED: Foreign language articles

1 Dottori L, D'Ottavio D, Brundisini B. (1982). [Calcifediol and calcitonin in the therapy of rheumatoid arthritis. A short-term controlled study]. Minerva Med.
2 Kaji H, Sugimoto T. (2005). [Treatment of osteoporosis with parathyroid hormone: evidence and perspective]. Clin Calcium.

## REJECTED: No outcome of interest

1 Ringe JD, Dorst A, Faber H, Kipshoven C, Rovati LC, Setnikar I. (2005). Efficacy of etidronate and sequential monofluorophosphate in severe postmenopausal osteoporosis: a pilot study. Rheumatol Int.
2 Ste-Marie LG, Schwartz SL, Hossain A, Desaiah D, Gaich GA. (2006). Effect of teriparatide [rhPTH(1–34)] on BMD when given to postmenopausal women receiving hormone replacement therapy. J Bone Miner Res.