# Appendix C Evidence Tables

## Evidence Table C1. Adverse Events

Evidence Table C1. Adverse Events

Author, Year, Drug, Country, Trial name | Adverse events reported
Abellan Perez M, 1995 ^1^ | Calcitonin+Calcium vs. Calcium:
| Arterial hypertension: 2.3%(1/43) vs. 0.0%(0/45)
| Flushing skin: 2.3%(1/43) vs. 0.0%(0/45)
| Gastrointestinal problems: 7.0%(3/43) vs. 0.0%(0/45)
Adachi JD et al., 1997 ^2^ | Etidronate vs. Placebo:
| Death: 1.5%(1/67) vs. 0.0%(0/74)
| Elevated serum creatinine level: 1.5%(1/67) vs. 0.0%(0/74)
| Gastrointestinal adverse effects: 19.4%(13/67) vs. 16.2%(12/74)
Adachi JD et al., 1997 ^3^ | Calcitonin vs. Placebo:
| Death: 6.3%(1/16) vs. 0.0%(0/15)
| Dizziness: 6.3%(1/16) vs. 0.0%(0/15)
| Rash: 6.3%(1/16) vs. 0.0%(0/15)
Adachi JD et al., 2001 ^4^ | Risedronate vs. Placebo:
| Any clinical adverse event: 42.9%(15/35) vs. 41.9%(13/31)
| Accidental injury: 0.0%(0/35) vs. 3.2%(1/31)
| Any upper GI tract AE: 20.0%(7/35) vs. 19.4%(6/31)
| Atrial fibrillation: 2.9%(1/35) vs. 0.0%(0/31)
| Cystitis: 2.9%(1/35) vs. 0.0%(0/31)
| Diarrhea: 0.0%(0/35) vs. 6.5%(2/31)
| Dry mouth: 0.0%(0/35) vs. 3.2%(1/31)
| Duodenitis: 2.9%(1/35) vs. 0.0%(0/31)
| Esophagitis: 2.9%(1/35) vs. 0.0%(0/31)
| Flatulence: 0.0%(0/35) vs. 3.2%(1/31)
| Gastrointestinal carcinoma: 0.0%(0/35) vs. 3.2%(1/31)
| Glossitis: 0.0%(0/35) vs. 3.2%(1/31)
| Headache: 0.0%(0/35) vs. 3.2%(1/31)
| Moderate to severe upper gastrointestinal adverse events: 11.4%(4/35) vs. 16.1%(5/31)
| Nausea: 0.0%(0/35) vs. 9.7%(3/31)
Adachi JD et al., 2001 ^5^ | Alendronate 10mg vs. Alendronate 5mg vs. Alendronate 2.5/10mg vs. Placebo:
| AE -all: 92.7%(51/55) vs. 93.7%(59/63) vs. 89.7%(26/29) vs. 90.2%(55/61)
| Abdominal pain: 7.3%(4/55) vs. 9.5%(6/63) vs. 10.3%(3/29) vs. 14.8%(9/61)
| Acid regurgitation: 9.1%(5/55) vs. 1.6%(1/63) vs. 0.0%(0/29) vs. 4.9%(3/61)
| Gastritis: 5.5%(3/55) vs. 1.6%(1/63) vs. 3.4%(1/29) vs. 3.3%(2/61)
| Nausea: 5.5%(3/55) vs. 4.8%(3/63) vs. 0.0%(0/29) vs. 4.9%(3/61)
| Reflux esophagitis: 7.3%(4/55) vs. 0.0%(0/63) vs. 0.0%(0/29) vs. 0.0%(0/61)
| Serious AE: 16.4%(9/55) vs. 22.2%(14/63) vs. 17.2%(5/29) vs. 31.1%(19/61)
| Serious upper GI AE: 1.8%(1/55) vs. 0.0%(0/63) vs. 0.0%(0/29) vs. 4.9%(3/61)
| Upper GI AE: 30.9%(17/55) vs. 20.6%(13/63) vs. 17.2%(5/29) vs. 31.1%(19/61)
Adami S et al., 1993 ^6^ | Alendronate 10 mg vs. Alendronate 20 mg vs. Calcitonin vs. Placebo:
| Cholelithiasis: 0.0%(0/68) vs. 0.0%(0/72) vs. 0.0%(0/75) vs. 1.4%(1/71)
| Unstable angina: 0.0%(0/68) vs. 0.0%(0/72) vs. 1.3%(1/75) vs. 0.0%(0/71)
| Upper GI AE: 13.2%(9/68) vs. 6.9%(5/72) vs. 5.3%(4/75) vs. 12.7%(9/71)
Adami S et al., 1995 ^7^ | Alendronate 10mg vs. Alendronate 20mg vs. Intranasal calcitonin 100iu vs. Placebo:
| increase in liver enzymes: 0.0%(0/68) vs. 1.4%(1/72) vs. 1.3%(1/75) vs. 0.0%(0/71)
| Drug related AE: 11.8%(8/68) vs. 8.3%(6/72) vs. 13.3%(10/75) vs. 5.6%(4/71)
| Eosinophilia: 1.5%(1/68) vs. 0.0%(0/72) vs. 0.0%(0/75) vs. 0.0%(0/71)
| Serious AE (non drug related): 1.5%(1/68) vs. 2.8%(2/72) vs. 4.0%(3/75) vs. 1.4%(1/71)
| Upper GI AE: 14.7%(10/68) vs. 11.1%(8/72) vs. 5.3%(4/75) vs. 14.1%(10/71)
Adami S et al., 2000 ^8^ | Etidronate+Calcium vs. Placebo+Calcium:
| Abdominal pain: 15.1%(8/53) vs. 13.0%(7/54)
| Adverse event: 43.4%(23/53) vs. 37.0%(20/54)
| Back pain: 5.7%(3/53) vs. 1.9%(1/54)
| Gastritis: 1.9%(1/53) vs. 1.9%(1/54)
| Hospitalization: 3.8%(2/53) vs. 3.7%(2/54)
| Severe depression: 1.9%(1/53) vs. 0.0%(0/54)
Adami S et al., 2004 ^9^ | Ibandronate 1mg vs. Ibandronate 2mg vs. Placebo:
| AE related to study medication: 20.0%(26/131) vs. 19.0%(50/261) vs. 14.0%(18/128)
| At least one AE: 75.0%(98/131) vs. 70.0%(183/261) vs. 71.0%(91/128)
| Cardiovascular system: 13.0%(17/131) vs. 10.0%(26/261) vs. 5.0%(6/128)
| Digestive system: 17.0%(22/131) vs. 17.0%(44/261) vs. 22.0%(28/128)
| Hemic and lymphatic system: 1.0%(1/131) vs. 5.0%(13/261) vs. 2.0%(3/128)
| Metabolic and nutritional disorders: 4.0%(5/131) vs. 2.0%(5/261) vs. 5.0%(6/128)
| Musculoskeletal system: 27.0%(35/131) vs. 24.0%(63/261) vs. 25.0%(32/128)
| Nervous system: 19.0%(25/131) vs. 13.0%(34/261) vs. 16.0%(20/128)
| Respiratory system: 32.0%(42/131) vs. 29.0%(76/261) vs. 30.0%(38/128)
| Skin and appendages: 10.0%(13/131) vs. 9.0%(23/261) vs. 7.0%(9/128)
| Special senses: 5.0%(7/131) vs. 2.0%(5/261) vs. 4.0%(5/128)
| Urogenital system: 12.0%(16/131) vs. 8.0%(21/261) vs. 9.0%(12/128)
Agrawal S et al., 2006 ^10^ | Risedronate vs. Placebo:
| AE - any clinical: 87.1%(27/31) vs. 89.7%(26/29)
| Any upper gastrointestinal AEs: 74.2%(23/31) vs. 72.4%(21/29)
| Drug-related AE: 35.5%(11/31) vs. 24.1%(7/29)
| Myocardial infarction - death: 3.2%(1/31) vs. 0.0%(0/29)
| Serious AE: 9.7%(3/31) vs. 3.4%(1/29)
| Upper GI AE - abdominal pain: 29.0%(9/31) vs. 6.9%(2/29)
| Upper GI AE - moderate to severe: 51.6%(16/31) vs. 58.6%(17/29)
Alexandersen P et al., 1999 ^11^ | Estrogen vs. Estrogen+Fluoride vs. Fluoride vs. Placebo:
| Breast tenderness, edema, headache, nausea, weight gain, mood change: 92.3%(24/26) vs. 96.0%(24/25) vs. 52.0%(13/25) vs. 12.5%(3/24)
| Endometrial bleeding: 23.1%(6/26) vs. 20.0%(5/25) vs. 8.0%(2/25) vs. 8.3%(2/24)
| Exanthema: 30.8%(8/26) vs. 8.0%(2/25) vs. 12.0%(3/25) vs. 33.3%(8/24)
| Joint pain, pain in extremities, heartburn: 19.2%(5/26) vs. 32.0%(8/25) vs. 28.0%(7/25) vs. 29.2%(7/24)
| Severe AEs: 0.0%(0/25) vs. 0.0%(0/24)
Amory JK et al., 2004 ^12^ | Testosterone vs. Testosterone+Finasteride vs. Placebo:
| Cerebral hemorrhage: 4.2%(1/24) vs. 0.0%(0/22) vs. 0.0%(0/24)
| Prostate cancer: 8.3%(2/24) vs. 0.0%(0/22) vs. 4.2%(1/24)
| Sleep apnea: 4.2%(1/24) vs. 0.0%(0/22) vs. 0.0%(0/24)
Anderson GL et al., 2003 ^13^ | Estrogen with progestin vs. Placebo:
| Borderline ovarian cancer: 0.0%(1/8506) vs. 0.0%(3/8102)
| Cervical cancer: 0.1%(8/8506) vs. 0.1%(5/8102)
| Endometrial cancer: 0.3%(27/8506) vs. 0.4%(31/8102)
| Invasive ovarian cancer: 0.2%(20/8506) vs. 0.1%(12/8102)
| Non-endometrial uterine cancer: 0.0%(1/8506) vs. 0.0%(0/8102)
| Other gynecologic cancer: 0.1%(6/8506) vs. 0.0%(1/8102)
Anderson GL et al., 2004 ^14^ | Estrogen vs. Placebo:
| Adjudicated deaths: 5.2%(278/5310) vs. 5.0%(272/5429)
| Breast cancer - death: 0.1%(4/5310) vs. 0.1%(8/5429)
| Cardiovascular - death: 1.8%(93/5310) vs. 1.7%(95/5429)
| Colorectal cancer: 1.1%(61/5310) vs. 1.1%(58/5429)
| Coronary Heart Disease: 3.3%(177/5310) vs. 3.7%(199/5429)
| Death: 5.5%(291/5310) vs. 5.3%(289/5429)
| Invasive breast cancer: 1.8%(94/5310) vs. 2.3%(124/5429)
| Other cancer - death: 2.1%(110/5310) vs. 2.2%(118/5429)
| Stroke: 3.0%(158/5310) vs. 2.2%(118/5429)
| Unknown cause - death: 0.4%(20/5310) vs. 0.2%(13/5429)
| Venous thromboembolic disease: 1.9%(101/5310) vs. 1.4%(78/5429)
Aris RM et al., 2000 ^15^ | Pamidronate vs. Control:
| Bone pain: 0.0%(0/16) vs. 0.0%(0/18)
| Cellulitis: 0.0%(0/16) vs. 0.0%(0/18)
| Fever: 0.0%(0/16) vs. 0.0%(0/18)
| Hypocalcemia: 0.0%(0/16) vs. 0.0%(0/18)
| Mild hypervitaminosis D: 0.0%(0/16) vs. 0.0%(0/18)
| Thrombophlebitis: 0.0%(0/16) vs. 0.0%(0/18)
Aris RM et al., 2004 ^16^ | Alendronate vs. Control:
| Death: 0.0%(0/24) vs. 4.2%(1/24)
| Diarrhea: 4.2%(1/24) vs. 8.3%(2/24)
| Dysphagia: 0.0%(0/24) vs. 0.0%(0/24)
| Nephrolithiasis: 4.2%(1/24) vs. 0.0%(0/24)
Ascott-Evans BH et al., 2003 ^17^ | Alendronate vs. Placebo:
| Clinical AE: 63.2%(60/95) vs. 61.2%(30/49)
| Hot flashes: 2.1%(2/95) vs. 10.2%(5/49)
| Serious AE: 0.0%(0/95) vs. 0.0%(0/49)
| Upper GI AE: 15.8%(15/95) vs. 12.2%(6/49)
Barrett-Connor E et al., 2002 ^18^ | Placebo total vs. Raloxifene 120mg vs. Raloxifene 60mg:
| Any cardiovascular (CV) event: 3.7%(96/2576) vs. 3.7%(94/2572) vs. 3.2%(82/2557)
| Any cerebrovascular event: 1.6%(41/2576) vs. 1.5%(39/2572) vs. 1.4%(37/2557)
| Any coronary event: 2.1%(55/2576) vs. 2.2%(56/2572) vs. 1.8%(45/2557)
| Coronary death, myocardial infarction, unstable angina: 1.7%(45/2576) vs. 1.7%(44/2572) vs. 1.5%(39/2557)
| Fatal CV event: 0.6%(15/2576) vs. 0.7%(19/2572) vs. 0.5%(12/2557)
| Fatal cerebrovascular event: 0.2%(6/2576) vs. 0.2%(6/2572) vs. 0.1%(3/2557)
| Fatal coronary event: 0.3%(9/2576) vs. 0.5%(13/2572) vs. 0.4%(9/2557)
| Incident MI by serial ECGs: 0.3%(9/2576) vs. 0.2%(5/2572) vs. 0.3%(8/2557)
| Incident MI or myocardial ischemia identified by serial ECGs: 4.3%(110/2576) vs. 3.5%(89/2572) vs. 3.5%(89/2557)
| Nonfatal CV event: 3.2%(82/2576) vs. 2.9%(75/2572) vs. 2.7%(70/2557)
| Nonfatal cerebrovascular event: 1.4%(36/2576) vs. 1.3%(33/2572) vs. 1.3%(34/2557)
| Nonfatal coronary event: 1.8%(46/2576) vs. 1.7%(43/2572) vs. 1.4%(36/2557)
Bartram SA et al., 2003 ^19^ | Calcium vs. Pamidronate+Calcium+Vitamin D:
| Flu-like symptoms 24hrs after infusion: 0.0%(0/37) vs. 8.1%(3/37)
| Nausea: 8.1%(3/37) vs. 0.0%(0/37)
Bauer DC et al., 2000 ^20^ | Alendronate vs. Placebo:
| Abdominal pain: 13.7%(443/3236) vs. 13.1%(422/3223)
| Acid regurgitation: 6.6%(214/3236) vs. 6.1%(197/3223)
| Anorexia: 0.7%(24/3236) vs. 0.9%(30/3223)
| Any UGI tract AE: 47.5%(1536/3236) vs. 46.2%(1490/3223)
| Any esophageal AE: 10.0%(322/3236) vs. 9.4%(303/3223)
| Any gastric or duodenal AE: 4.0%(130/3236) vs. 4.0%(129/3223)
| Any gastric or duodenal perforations, ulcers, bleeding: 1.6%(53/3236) vs. 1.9%(61/3223)
| Barrett's esophagus: 0.0%(1/3236) vs. 0.0%(0/3223)
| Duodenitis: 0.2%(7/3236) vs. 0.1%(4/3223)
| Dyspepsia: 18.2%(588/3236) vs. 19.1%(617/3223)
| Dysphagia: 0.7%(23/3236) vs. 0.7%(24/3223)
| Erosive esophagitis: 0.1%(2/3236) vs. 0.0%(0/3223)
| Esophagalgia: 0.2%(6/3236) vs. 0.1%(2/3223)
| Esophageal stricture: 0.3%(10/3236) vs. 0.2%(7/3223)
| Esophageal ulcer: 0.2%(7/3236) vs. 0.2%(6/3223)
| Esophagitis: 0.7%(24/3236) vs. 0.4%(14/3223)
| Gastritis: 2.5%(82/3236) vs. 2.3%(75/3223)
| Hemorrhage, GI: 0.1%(4/3236) vs. 0.2%(7/3223)
| Nausea: 10.9%(354/3236) vs. 11.8%(379/3223)
| Odynophagia: 0.1%(2/3236) vs. 0.0%(0/3223)
| Reflux esophagitis: 2.0%(65/3236) vs. 2.2%(72/3223)
| Serious UGI AE requiring hospitalization: 2.0%(65/3236) vs. 1.8%(59/3223)
| Serious esophageal AEs: 0.3%(11/3236) vs. 0.2%(5/3223)
| Ulcer gastric: 0.8%(26/3236) vs. 0.8%(27/3223)
| Ulcer, duodenal: 0.1%(4/3236) vs. 0.3%(11/3223)
| Ulcer, duodenal with hemorrhage: 0.1%(3/3236) vs. 0.0%(1/3223)
| Ulcer, gastric with hemorrhage: 0.3%(9/3236) vs. 0.2%(6/3223)
| Ulcer, gastrojejunal: 0.0%(1/3236) vs. 0.0%(0/3223)
| Ulcer, peptic: 0.3%(10/3236) vs. 0.4%(13/3223)
| Ulcer, peptic with hemorrhage: 0.0%(0/3236) vs. 0.0%(1/3223)
| Vomiting: 3.4%(110/3236) vs. 3.1%(99/3223)
Baum M et al., 2002 ^21^ | Anastrozole vs. Tamoxifen vs. Tamoxifen+Anastrozole:
| All deaths: 6.4%(200/3125) vs. 6.5%(203/3116) vs. 6.9%(215/3125)
| Any venous thrombembolic event: 2.0%(64/3125) vs. 3.5%(109/3116) vs. 4.0%(124/3125)
| Cataracts: 3.4%(107/3125) vs. 3.7%(116/3116) vs. 3.4%(105/3125)
| Colorectal cancer: 0.8%(24/3125) vs. 0.6%(19/3116) vs. 0.3%(9/3125)
| Contralateral breast cancer: 0.4%(14/3125) vs. 1.1%(33/3116) vs. 0.9%(28/3125)
| Deaths after recurrence: 3.9%(122/3125) vs. 3.9%(122/3116) vs. 4.6%(145/3125)
| Deaths before recurrence: 2.5%(78/3125) vs. 2.6%(81/3116) vs. 2.2%(70/3125)
| Deep venous thromboembolic events including PE: 1.0%(32/3125) vs. 1.7%(54/3116) vs. 2.0%(63/3125)
| Distant recurrence of breast cancer as a first event: 5.1%(158/3125) vs. 5.8%(182/3116) vs. 6.5%(204/3125)
| Ductal carcinoma in situ: 0.2%(5/3125) vs. 0.1%(3/3116) vs. 0.2%(5/3125)
| Endometrial cancer: 0.1%(3/3125) vs. 0.4%(13/3116) vs. 0.2%(6/3125)
| Fatigue/tiredness: 15.5%(483/3125) vs. 15.0%(466/3116) vs. 13.9%(435/3125)
| Head and neck cancer: 0.2%(5/3125) vs. 0.2%(5/3116) vs. 0.2%(5/3125)
| Hot flushes: 33.9%(1060/3125) vs. 39.4%(1229/3116) vs. 39.8%(1243/3125)
| Invasive breast cancer: 0.3%(9/3125) vs. 1.0%(30/3116) vs. 0.7%(23/3125)
| Ischemic cardiovascular disease: 2.4%(76/3125) vs. 1.9%(59/3116) vs. 2.2%(68/3125)
| Ischemic cerebrovascular event: 1.0%(31/3125) vs. 2.1%(65/3116) vs. 1.6%(51/3125)
| Local recurrence of breast cancer: 2.1%(67/3125) vs. 2.7%(83/3116) vs. 2.6%(81/3125)
| Lung cancer: 0.3%(8/3125) vs. 0.2%(7/3116) vs. 0.1%(4/3125)
| Melanoma: 0.0%(0/3125) vs. 0.2%(6/3116) vs. 0.0%(1/3125)
| Mood disturbances: 15.4%(480/3125) vs. 15.1%(469/3116) vs. 15.4%(482/3125)
| Musculoskeletal disorders: 27.5%(860/3125) vs. 21.2%(660/3116) vs. 21.9%(685/3125)
| Nausea and vomiting: 10.4%(324/3125) vs. 10.1%(315/3116) vs. 11.6%(363/3125)
| Other cancers: 0.7%(22/3125) vs. 0.9%(28/3116) vs. 0.9%(29/3125)
| Ovarian cancer: 0.2%(6/3125) vs. 0.3%(9/3116) vs. 0.2%(6/3125)
| Recurrence of breast cancer year 1: 2.5%(77/3125) vs. 2.3%(71/3116) vs. 2.8%(87/3125)
| Recurrence of breast cancer year 2: 2.5%(78/3125) vs. 4.1%(127/3116) vs. 3.9%(123/3125)
| Recurrence of breast cancer year 3: 2.0%(64/3125) vs. 2.5%(77/3116) vs. 2.6%(80/3125)
| Skin cancer: 1.2%(39/3125) vs. 1.0%(32/3116) vs. 0.9%(27/3125)
| Vaginal bleeding: 4.4%(138/3125) vs. 8.1%(253/3116) vs. 7.6%(238/3125)
| Vaginal discharge: 2.8%(86/3125) vs. 11.4%(354/3116) vs. 11.4%(357/3125)
Bekker PJ et al., 2004 ^22^ | AMG 162 0.01mg/kg vs. AMG 162 0.03mg/kg vs. AMG 162 0.1mg/kg vs. AMG 162 0.3mg/kg vs. AMG 162 1mg/kg vs. AMG 162 3mg/kg vs. Placebo:
| Injection site pain: 0.0%(0/6) vs. 0.0%(0/6) vs. 0.0%(0/6) vs. 0.0%(0/6) vs. 16.7%(1/6) vs. 0.0%(0/7) vs. 0.0%(0/12)
| Injection site rash and burning: 0.0%(0/6) vs. 0.0%(0/6) vs. 0.0%(0/6) vs. 0.0%(0/6) vs. 0.0%(0/6) vs. 14.3%(1/7) vs. 0.0%(0/12)
Bell NH et al., 2002 ^23^ | Alendronate vs. Placebo:
| Any AE: 90.9%(30/33) vs. 93.8%(30/32)
| Abdominal distension: 0.0%(0/33) vs. 3.1%(1/32)
| Abdominal pain: 21.2%(7/33) vs. 9.4%(3/32)
| Acid regurgitation: 3.0%(1/33) vs. 0.0%(0/32)
| Anorexia: 3.0%(1/33) vs. 0.0%(0/32)
| Any UGI AE: 42.4%(14/33) vs. 34.4%(11/32)
| Any serious AE: 9.1%(3/33) vs. 15.6%(5/32)
| Diaphragmatic hernia: 0.0%(0/33) vs. 3.1%(1/32)
| Dyspepsia: 3.0%(1/33) vs. 9.4%(3/32)
| Gastritis: 3.0%(1/33) vs. 0.0%(0/32)
| Gastric atony: 0.0%(0/33) vs. 3.1%(1/32)
| Gastric reflux: 3.0%(1/33) vs. 0.0%(0/32)
| Nausea: 6.1%(2/33) vs. 6.3%(2/32)
Black DM et al., 1996 ^24^ | Alendronate vs. Placebo:
| Abdominal pain: 11.8%(121/1022) vs. 9.8%(98/1005)
| Acid regurgitation/reflux: 6.9%(71/1022) vs. 7.1%(71/1005)
| Any upper-gastrointestinal event: 41.3%(422/1022) vs. 40.0%(402/1005)
| Death: 2.3%(24/1022) vs. 2.1%(21/1005)
| Duodenal ulcer: 0.2%(2/1022) vs. 0.6%(6/1005)
| Dyspepsia: 15.2%(155/1022) vs. 15.7%(158/1005)
| Gastric ulcer: 0.7%(7/1022) vs. 1.6%(16/1005)
| Gastritis: 2.3%(24/1022) vs. 2.0%(20/1005)
| Nausea: 9.4%(96/1022) vs. 9.7%(97/1005)
| Esophageal ulcer: 0.3%(3/1022) vs. 0.2%(2/1005)
| Esophagitis: 0.7%(7/1022) vs. 0.4%(4/1005)
| Other gastric: 0.4%(4/1022) vs. 0.2%(2/1005)
| Other esophageal: 1.6%(16/1022) vs. 1.1%(11/1005)
| Peptic ulcer: 0.3%(3/1022) vs. 0.7%(7/1005)
| Total AE resulting in hospital admission: 24.5%(250/1022) vs. 29.9%(300/1005)
Black DM et al., 2007 ^25^ | Zoledronic acid vs Placebo:
| Any adverse event: 94.8%(3688/3889) vs 93.3%(3616/3876)
| Any serious adverse event: 29.0%(1126/3889) vs 29.9%(1158/3876)
| Arthralgia: 6.3%(245/3889) vs 2.0%(76/3876)
| Atrial fibrillation: Any event: 2.4%(94/3889) vs 1.9%(73/3876)
| Atrial fibrillation: Serious adverse event: 1.3%(50/3889) vs 0.5%(20/3876)
| Death: 3.3%(130/3889) vs 2.9%(112/3876)
| Death from cardiovascular causes: 1.0%(39/3889) vs 0.9%(33/3876)
| Headache: 7.0%(273/3889) vs 2.3%(90/3876)
| Influenza-like symptoms: 7.7%(301/3889) vs 1.6%(61/3876)
| Myalgia: 9.4%(365/3889) vs 1.7%(66/3876)
| Myocardial infarction: 1.0%(38/3889) vs 1.2%(45/3876)
| Pyrexia: 16.0%(621/3889) vs 2.0%(79/3876)
| Renal: Calculated creatinine clearance <30 ml/min: 4.1%(160/3889) vs 3.9%(152/3876)
| Renal: Increase in serum creatinine >0.5 mg/dl: 0.8%(31/3889) vs 0.3%(10/3876)
| Renal: Urinary protein >2+: 0.3%(13/3889) vs 0.1%(5/3876)
| Stroke: Death from stroke: 0.5%(20/3889) vs 0.3%(11/3876)
| Stroke: Serious adverse event: 2.2%(87/3889) vs 2.3%(88/3876)
Blumel JE et al., 2003 ^26^ | Alendronate 10 mg/day vs. Alendronate 70 mg once a wk vs. Enteric alendronate 70 mg per wk:
| Headache: 4.0%(1/25) vs. 4.0%(1/25) vs. 4.0%(1/25)
| Heartburn: 28.0%(7/25) vs. 12.0%(3/25) vs. 8.0%(2/25)
| Nausea: 0.0%(0/25) vs. 4.0%(1/25) vs. 0.0%(0/25)
Body JJ et al., 2002 ^27^ | Alendronate vs. PTH:
| Death from cardiac arrest: 0.0%(0/73) vs. 1.0%(1/73)
| Leg cramps: 0.0%(0/73) vs. 8.2%(6/73)
| New or worsened back pain: 19.2%(14/73) vs. 5.5%(4/73)
| Positive test for antiteriparatide antibodies: 0.0%(0/73) vs. 4.1%(3/73)
Bone HG et al., 1997 ^28^ | Alendronate 1mg vs. Alendronate 2.5mg vs. Alendronate 5mg vs. Placebo:
| Drug related AEs: 19.8%(17/86) vs. 25.8%(23/89) vs. 17.2%(16/93) vs. 23.1%(21/91)
Bone HG et al., 2000 ^29^ | Alendronate vs. Alendronate+Estrogen vs. Estrogen vs. Placebo:
| Any adverse experience: 87.0%(80/92) vs. 92.9%(130/140) vs. 90.2%(129/143) vs. 90.0%(45/50)
| Abdominal pain: 7.6%(7/92) vs. 7.9%(11/140) vs. 6.3%(9/143) vs. 4.0%(2/50)
| Any serious adverse experience: 14.1%(13/92) vs. 13.6%(19/140) vs. 11.9%(17/143) vs. 10.0%(5/50)
| Any upper gastrointestinal adverse experiences: 27.2%(25/92) vs. 33.6%(47/140) vs. 30.1%(43/143) vs. 22.0%(11/50)
| Dyspepsia: 7.6%(7/92) vs. 5.7%(8/140) vs. 6.3%(9/143) vs. 6.0%(3/50)
| Esophageal irritation: 5.4%(5/92) vs. 3.6%(5/140) vs. 3.5%(5/143) vs. 4.0%(2/50)
| Peptic ulcer: 0.0%(0/92) vs. 1.4%(2/140) vs. 0.0%(0/143) vs. 0.0%(0/50)
Bone HG et al., 2004 ^30^ | 10 mg alendronate for 10 yrs vs. 20 mg alendronate for 2 yrs+5 mg alendronate for 3 yrs+placebo for 5 yrs vs. 5-mg_alendronate group for 10 yrs:
| Any clinical AE: 89.5%(77/86) vs. 92.8%(77/83) vs. 94.9%(74/78)
| At least one upper GI event: 27.9%(24/86) vs. 24.1%(20/83) vs. 14.1%(11/78)
| Death: 0.0%(0/86) vs. 0.0%(0/83) vs. 5.1%(4/78)
| Duodenal ulcer: 0.0%(0/86) vs. 0.0%(0/83) vs. 1.3%(1/78)
| Dysphagia: 0.0%(0/86) vs. 2.4%(2/83) vs. 0.0%(0/78)
| Erosive esophagitis: 0.0%(0/86) vs. 2.4%(2/83) vs. 1.3%(1/78)
| Esophagalgia: 1.2%(1/86) vs. 0.0%(0/83) vs. 0.0%(0/78)
| Esophageal AE: 2.3%(2/86) vs. 7.2%(6/83) vs. 1.3%(1/78)
| Esophagitis: 1.2%(1/86) vs. 1.2%(1/83) vs. 0.0%(0/78)
| Odynophagia: 0.0%(0/86) vs. 1.2%(1/83) vs. 0.0%(0/78)
| Serious any clinical event: 20.9%(18/86) vs. 21.7%(18/83) vs. 32.1%(25/78)
| Serious upper gastrointestinal even: 0.0%(0/86) vs. 1.2%(1/83) vs. 1.3%(1/78)
Bonnick S et al., 2006 ^31^ | Alendronate vs. Risedronate:
| Death due to upper gastrointestinal AE - hemorrhagic duodenal ulcer: 0.0%(0/520) vs. 0.2%(1/533)
| Duodenal ulcer: 0.2%(1/520) vs. 0.0%(0/533)
| Gastroesophageal reflux disease: 0.0%(0/520) vs. 0.2%(1/533)
| One or more AEs: 87.1%(453/520) vs. 86.5%(461/533)
| One or more upper gastrointestinal AE: 19.6%(102/520) vs. 17.8%(95/533)
| Serious AE: 12.4%(64/520) vs. 13.5%(72/533)
Boutsen Y et al., 1997 ^32^ | Calcium vs. Pamidronate:
| Death - Severe pulmonary infection: 7.7%(1/13) vs. 0.0%(0/14)
| Mild hypercalciuria: 7.7%(1/13) vs. 7.1%(1/14)
Brown JP et al., 2001 ^33^ | Etidronate vs. Placebo:
| Moderate to severe upper gastrointestinal adverse effect: 7.5%(4/53) vs. 4.9%(3/61)
Brown JP et al., 2002 ^34^ | Risedronate 35 mg vs. Risedronate 5 mg vs. Risedronate 50 mg:
| Any upper GI tract event: 18.4%(89/485) vs. 17.5%(84/480) vs. 18.7%(92/491)
| Arthralgia: 14.2%(69/485) vs. 11.5%(55/480) vs. 13.4%(66/491)
| Constipation: 12.2%(59/485) vs. 12.5%(60/480) vs. 12.2%(60/491)
| Infection: 20.6%(100/485) vs. 19.0%(91/480) vs. 20.2%(99/491)
| Moderate to severe upper GI tract event: 4.5%(22/485) vs. 4.8%(23/480) vs. 4.3%(21/491)
| Serious (fatal, life threatening, etc.) clinical event: 8.2%(40/485) vs. 7.1%(34/480) vs. 9.2%(45/491)
Brumsen C et al., 2002 ^35^ | Pamidronate vs. Placebo:
| Colon cancer: 2.0%(1/51) vs. 0.0%(0/50)
| Duodenal ulcer: 2.0%(1/51) vs. 0.0%(0/50)
| Esophagitis: 2.0%(1/51) vs. 4.0%(2/50)
| Histomorphometric AEs: 0.0%(0/51) vs. 0.0%(0/50)
| Obstructive cholestatic disease: 0.0%(0/51) vs. 2.0%(1/50)
| Transient increase AST/ALT/GGT: 2.0%(1/51) vs. 4.0%(2/50)
Campbell IA et al., 2004 ^36^ | Calcium vs. Etidronate vs. Etidronate+Calcium vs. Placebo:
| Death: 23.5%(20/85) vs. 9.9%(8/81) vs. 15.9%(14/88) vs. 15.8%(15/95)
| Headaches: 1.2%(1/85) vs. 2.5%(2/81) vs. 0.0%(0/95)
| Hypercalcemia: 1.2%(1/85) vs. 0.0%(0/81) vs. 0.0%(0/95)
| Nausea/vomiting/diarrhea/abdominal pain: 4.7%(4/85) vs. 12.3%(10/81) vs. 0.0%(0/95)
| Non-specifically unwell: 0.0%(0/85) vs. 2.5%(2/81) vs. 0.0%(0/95)
Chailurkit LO et al., 2003 ^37^ | Alendronate vs. Placebo:
| Abdominal pain: 2.5%(1/40) vs. 0.0%(0/40)
| Asthma: 0.0%(0/40) vs. 2.5%(1/40)
| Musculoskeletal pain: 2.5%(1/40) vs. 0.0%(0/40)
| Myocardial infarction resulting in death: 2.5%(1/40) vs. 0.0%(0/40)
Chen M et al., 2001 ^38^ | Estrogen+Calcium vs. Estrogen+Calcium+Vitamin D:
| Intolerable breast tenderness: 6.7%(8/120) vs. 2.5%(3/120)
| Irregular uterine bleeding: 15.8%(19/120) vs. 14.2%(17/120)
Cherry N et al., 2002 ^39^ | Estrogen vs. Placebo:
| Breast cancer: 0.8%(4/513) vs. 0.8%(4/504)
| Cardiac death: 4.1%(21/513) vs. 6.0%(30/504)
| Death from any cause: 6.2%(32/513) vs. 7.7%(39/504)
| Deep vein thrombosis: 0.4%(2/513) vs. 0.2%(1/504)
| Endometrial cancer: 0.0%(0/513) vs. 0.0%(0/504)
| Pulmonary embolism: 0.6%(3/513) vs. 0.6%(3/504)
| Reinfarction or cardiac death: 12.1%(62/513) vs. 12.1%(61/504)
| Stroke: 1.9%(10/513) vs. 1.2%(6/504)
| Transient ischemic attack: 2.9%(15/513) vs. 2.6%(13/504)
| Vaginal bleeding: 40.5%(208/513) vs. 5.2%(26/504)
Chesnut CH et al., 1995 ^40^ | Alendronate 10mg vs. Alendronate 20mg vs. Alendronate 40 mg vs. Alendronate 40mg/2.5mg vs. Alendronate 5mg vs. Placebo:
| Death - chronic obstructive pulmonary disease: 0.0%(0/30) vs. 0.0%(0/32) vs. 0.0%(0/32) vs. 0.0%(0/31) vs. 3.1%(1/32) vs. 0.0%(0/31)
| Rash: 0.0%(0/30) vs. 3.1%(1/32) vs. 0.0%(0/32) vs. 0.0%(0/31) vs. 0.0%(0/32) vs. 0.0%(0/31)
Chesnut CH et al., 2000 ^41^ | Nasal spray salmon calcitonin (100 iu) vs. Nasal spray salmon calcitonin (200 iu) vs. Nasal spray salmon calcitonin (400 iu) vs. Placebo:
| AE or illness not related to drug: 15.8%(50/316) vs. 16.1%(51/316) vs. 18.3%(57/312) vs. 18.0%(56/311)
| Drug-related AE: 6.6%(21/316) vs. 6.0%(19/316) vs. 9.9%(31/312) vs. 6.8%(21/311)
| Headache: 4.0%(38/944) vs. 7.0%(22/311)
| Rhinitis (nasal congestion, nasal discharge, or sneezing): 22.0%(208/944) vs. 15.0%(47/311)
Chesnut CH et al., 2004 ^42^ | Ibandronate 2.5mg vs. Ibandronate 20mg vs. Placebo:
| Any AE: 90.9%(888/977) vs. 91.9%(898/977) vs. 88.9%(867/975)
| Any AE leading to death: 1.1%(11/977) vs. 0.8%(8/977) vs. 1.0%(10/975)
| Any drug related AE: 19.8%(193/977) vs. 18.5%(181/977) vs. 17.9%(175/975)
| Any drug related serious AE: 0.3%(3/977) vs. 0.7%(7/977) vs. 0.3%(3/975)
| Any serious AE: 24.0%(234/977) vs. 25.3%(247/977) vs. 21.6%(211/975)
| Belching: 0.4%(4/977) vs. 0.5%(5/977) vs. 0.2%(2/975)
| Duodenal ulcer: 0.1%(1/977) vs. 0.1%(1/977) vs. 0.9%(9/975)
| Dyspepsia: 11.4%(111/977) vs. 9.0%(88/977) vs. 9.1%(89/975)
| Esophageal ulcer: 0.2%(2/977) vs. 0.1%(1/977) vs. 0.1%(1/975)
| Esophageal stenosis: 0.2%(2/977) vs. 0.0%(0/977) vs. 0.1%(1/975)
| Esophagitis: 1.5%(15/977) vs. 1.0%(10/977) vs. 1.0%(10/975)
| GI pain: 1.9%(19/977) vs. 2.5%(24/977) vs. 2.6%(25/975)
| Gastritis: 2.3%(22/977) vs. 1.2%(12/977) vs. 2.2%(21/975)
| Gastroenteritis: 5.5%(54/977) vs. 6.3%(62/977) vs. 5.5%(54/975)
| Nausea: 4.2%(41/977) vs. 6.4%(63/977) vs. 6.3%(61/975)
| Stomach ulcer: 0.3%(3/977) vs. 0.5%(5/977) vs. 0.6%(6/975)
| Vomiting: 3.0%(29/977) vs. 2.8%(27/977) vs. 2.5%(24/975)
Chlebowski RT et al., 2003 ^43^ | Conjugated equine estrogens 0.625 mg/d & medroxyprogesterone acetate 2.5 mg/d vs. Placebo:
| Invasive breast cancer: 2.3%(199/8506) vs. 1.9%(150/8102)
Chlebowski RT et al., 2004 ^44^ | Estrogen with progestin vs. Placebo:
| Death - colorectal cancer: 0.1%(9/8506) vs. 0.1%(8/8102)
| Invasive colon cancer: 0.4%(35/8506) vs. 0.8%(61/8102)
| Invasive rectal cancer: 0.1%(8/8506) vs. 0.1%(11/8102)
| Non-invasive colorectal cancer - carcinoids: 0.0%(2/8506) vs. 0.0%(0/8102)
| Non-invasive colorectal cancer - squamous cell: 0.0%(0/8506) vs. 0.0%(1/8102)
| Non-invasive colorectal cancer - stage 0 carcinoma in situ: 0.0%(3/8506) vs. 0.0%(1/8102)
| Other non-invasive colorectal cancer: 0.5%(43/8506) vs. 0.9%(72/8102)
| Vaginal bleeding in first year: 58.0%(4933/8506) vs. 7.0%(567/8102)
Chow CC et al., 2003 ^45^ | Alendronate vs. Placebo:
| 1st degree heart block due to beta-blocker treatment: 0.0%(0/20) vs. 5.0%(1/20)
| Beta-blocker-induced heart block: 0.0%(0/20) vs. 5.0%(1/20)
| Dizziness & fall (hospitalized): 5.0%(1/20) vs. 0.0%(0/20)
| Ibuprofen-induced gastric ulcer: 0.0%(0/20) vs. 5.0%(1/20)
| Methyldopa-induced hemolytic anemia: 5.0%(1/20) vs. 0.0%(0/20)
Ciuffetti G et al., 1991 ^46^ | Calcitonin vs. Placebo:
| Flushing skin: 10.0%(1/10) vs. 0.0%(0/10)
Clemmesen B et al., 1997 ^47^ | Continuous Risedronate vs. Cyclical Risedronate vs. Placebo:
| Esophagus GI AE: 2.3%(1/44) vs. 6.8%(3/44) vs. 0.0%(0/44)
| UGI AE moderate to severe: 6.8%(3/44) vs. 6.8%(3/44) vs. 6.8%(3/44)
Cohen S et al., 1999 ^48^ | Risedronate 2.5mg vs. Risedronate 5mg vs. Placebo:
| Abdominal pain: 8.0%(6/75) vs. 7.9%(6/76) vs. 5.2%(4/77)
| Death - pulmonary embolism: 1.0%(1/75) vs. 0.0%(0/76) vs. 0.0%(0/77)
| Diarrhea: 4.0%(3/75) vs. 10.5%(8/76) vs. 3.9%(3/77)
| Duodenitis: 0.0%(0/75) vs. 1.3%(1/76) vs. 0.0%(0/77)
| Dyspepsia: 6.7%(5/75) vs. 3.9%(3/76) vs. 9.1%(7/77)
| Esophageal erosion: 0.0%(0/75) vs. 0.0%(0/76) vs. 1.3%(1/77)
| Gastritis: 1.3%(1/75) vs. 1.3%(1/76) vs. 0.0%(0/77)
| Hiatal hernia: 0.0%(0/75) vs. 1.3%(1/76) vs. 1.3%(1/77)
| Moderate-to-severe upper GI AE: 6.8%(5/75) vs. 5.3%(4/76) vs. 5.3%(4/77)
| Musculoskeletal: 45.3%(34/75) vs. 48.7%(37/76) vs. 48.1%(37/77)
| Nausea: 2.7%(2/75) vs. 7.9%(6/76) vs. 6.5%(5/77)
| Serious adverse events: 20.0%(15/75) vs. 22.4%(17/76) vs. 26.0%(20/77)
| Upper gastrointestinal: 20.0%(15/75) vs. 14.5%(11/76) vs. 16.9%(13/77)
Combe B et al., 1997 ^49^ | Intranasal calcitonin 200iu vs. Subcutaneous calcitonin 50iu:
| Atrophic mucosa w/ local irritation: 0.0%(0/102) vs. 1.0%(1/102)
| Ears, nose, throat: 2.0%(2/102) vs. 2.0%(2/102)
| GI disorders: 1.0%(1/102) vs. 2.9%(3/102)
| Inflammatory olfactory mucosa: 1.0%(1/102) vs. 0.0%(0/102)
| Nausea, vomiting: 10.8%(11/102) vs. 17.6%(18/102)
| Neutropenia: 0.0%(0/102) vs. 1.0%(1/102)
| Rhinitis, rhinorrhea, hydrorrhea: 8.8%(9/102) vs. 9.8%(10/102)
| Sneezing, tingling: 15.7%(16/102) vs. 10.8%(11/102)
| Vasomotor flushes: 13.7%(14/102) vs. 14.7%(15/102)
Cooper C et al., 2003 ^50^ | Ibandronate (daily 2.5 mg) vs. Ibandronate (weekly 20 mg):
| Any AEs: 81.8%(99/121) vs. 78.1%(89/114)
| AE for Digestive System: 29.8%(36/121) vs. 23.7%(27/114)
| Constipation: 6.0%(7/121) vs. 4.0%(5/114)
| Death: 0.0%(0/121) vs. 0.0%(0/114)
| Drug-related AEs: 31.4%(38/121) vs. 34.2%(39/114)
| Drug-related serious AEs: 0.0%(0/121) vs. 0.0%(0/114)
| Dyspepsia: 9.0%(11/121) vs. 6.0%(7/114)
| GI AE: 33.0%(40/121) vs. 28.0%(32/114)
| General Body: 23.0%(28/121) vs. 29.0%(33/114)
| Incidence of digestive system AE possibly related to study medication: 22.0%(27/121) vs. 16.0%(18/114)
| Musculoskeletal: 26.0%(31/121) vs. 28.0%(32/114)
| Serious AEs: 9.9%(12/121) vs. 7.9%(9/114)
Cortet B et al., 1999 ^51^ | Etidronate vs. Placebo:
| Abdominal pains: 14.0%(6/44) vs. 18.0%(7/39)
| At least one unwanted event: 84.0%(37/44) vs. 87.0%(34/39)
| Gastrointestinal: 32.0%(14/44) vs. 31.0%(12/39)
Cortet B et al., 2001 ^52^ | Alendronate vs. Etidronate:
| Abdominal distension: 4.3%(2/46) vs. 0.0%(0/53)
| Diarrhea: 2.2%(1/46) vs. 0.0%(0/53)
| Epigastric pain: 8.7%(4/46) vs. 0.0%(0/53)
| Osteomalacia: 0.0%(0/46) vs. 1.9%(1/53)
Cosman F et al., 2001 ^53^ | Estrogen vs. Estrogen+ PTH:
| Back pain: 0.0%(0/25) vs. 3.7%(1/27)
| Breast cancer: 0.0%(0/25) vs. 3.7%(1/27)
| Depression: 0.0%(0/25) vs. 3.7%(1/27)
| Increased back pain: 0.0%(0/25) vs. 3.7%(1/27)
| New diagnosis of breast cancer: 0.0%(0/25) vs. 3.7%(1/27)
| New diagnosis of otosclerosis: 0.0%(0/25) vs. 3.7%(1/27)
| Nodules at injection site: 0.0%(0/25) vs. 7.4%(2/27)
| Otosclerosis: 0.0%(0/25) vs. 3.7%(1/27)
| Skin modules: 0.0%(0/25) vs. 3.7%(1/27)
| UTI and possible undocumented kidney stone: 0.0%(0/25) vs. 3.7%(1/27)
Cosman F et al., 2005 ^54^ | Alendronate 70mg + cyclical PTH vs. Alendronate 70mg + daily PTH vs. Alendronate 70mg weekly:
| Abnormal CBD: 10.0%(4/40) vs. 11.6%(5/43) vs. 4.7%(2/43)
| Breast cancer: 0.0%(0/40) vs. 0.0%(0/43) vs. 2.3%(1/43)
| Cardiac symptoms: 7.5%(3/40) vs. 11.6%(5/43) vs. 7.0%(3/43)
| Death from complications of aortic-valve surgery: 0.0%(0/40) vs. 0.0%(0/43) vs. 2.3%(1/43)
| GI effects: 17.5%(7/40) vs. 20.9%(9/43) vs. 9.3%(4/43)
| Generalized fatigue: 7.5%(3/40) vs. 4.7%(2/43) vs. 0.0%(0/43)
| Increase liver function tests: 0.0%(0/40) vs. 2.3%(1/43) vs. 4.7%(2/43)
| Increase serum creatinine: 0.0%(0/40) vs. 0.0%(0/43) vs. 0.0%(0/43)
| Increase total serum calcium: 2.5%(1/40) vs. 2.3%(1/43) vs. 0.0%(0/43)
| Increase urinary calcium: creatinine ratio: 15.0%(6/40) vs. 34.9%(15/43) vs. 7.0%(3/43)
| Musculoskeletal symptoms: 10.0%(4/40) vs. 23.3%(10/43) vs. 4.7%(2/43)
| Redness at injection site: 15.0%(6/40) vs. 2.3%(1/43) vs. 0.0%(0/43)
| Rheumatoid arthritis: 2.5%(1/40) vs. 0.0%(0/43) vs. 0.0%(0/43)
| Vascular symptoms: 2.5%(1/40) vs. 4.7%(2/43) vs. 0.0%(0/43)
Crawford BA et al., 2006 ^55^ | Placebo vs. Zoledronic acid:
| Graft failure - death: 6.7%(2/30) vs. 0.0%(0/32)
| Hypocalcemia: 10.0%(3/30) vs. 40.6%(13/32)
| Nephrotic syndrome: 0.0%(0/30) vs. 3.1%(1/32)
| Sepsis: 3.3%(1/30) vs. 3.1%(1/32)
| Sepsis - death: 0.0%(0/30) vs. 3.1%(1/32)
| Suicide: 3.3%(1/30) vs. 0.0%(0/32)
Cryer B et al., 2005 ^56^ | Alendronate vs. Placebo:
| Abdominal pain: 4.5%(10/224) vs. 0.9%(2/226)
| Dyspepsia: 1.8%(4/224) vs. 2.7%(6/226)
| Heartburn: 0.9%(2/224) vs. 1.8%(4/226)
| Nausea: 2.7%(6/224) vs. 3.5%(8/226)
| Upper GI AE: 13.4%(30/224) vs. 11.1%(25/226)
| Vomiting: 1.8%(4/224) vs. 0.0%(0/226)
Cryer B et al., 2005 ^57^ | Alendronate vs. Placebo:
| Any clinical AE: 63.5%(141/224) vs. 52.6%(120/230)
| Abdominal distention: 2.7%(6/224) vs. 0.4%(1/230)
| Abdominal pain: 2.7%(6/224) vs. 1.3%(3/230)
| Any upper gastrointestinal AE: 23.7%(64/224) vs. 13.9%(32/230)
| Dyspepsia: 4.9%(11/224) vs. 3.9%(9/230)
| Endoscopically documented esophagitis: 0.0%(0/224) vs. 0.4%(1/230)
| Eructation: 3.1%(7/224) vs. 0.0%(0/230)
| Esophageal AE: 4.0%(9/224) vs. 3.0%(7/230)
| Gastroesophageal reflux disease (GERD): 1.3%(3/224) vs. 1.3%(3/230)
| Mild nausea: 58.0%(130/224) vs. 80.0%(184/230)
| Moderate nausea: 33.0%(74/224) vs. 20.0%(46/230)
| Nausea: 7.6%(17/224) vs. 4.3%(10/230)
| Serious AE: 4.1%(9/224) vs. 3.5%(8/230)
| Serious upper gastrointestinal AE - abdominal pain and nausea: 0.0%(0/224) vs. 0.4%(1/230)
| Upper abdominal pain: 4.0%(9/224) vs. 1.3%(3/230)
| Vomiting: 2.2%(5/224) vs. 1.3%(3/230)
Cummings SR et al., 1998 ^58^ | Alendronate vs. Placebo:
| Abdominal pain: 14.5%(322/2214) vs. 14.7%(325/2218)
| Acid regurgitation/reflux: 9.2%(204/2214) vs. 8.7%(194/2218)
| Any AE resulting in hospitalization: 29.1%(644/2214) vs. 26.9%(596/2218)
| Any UGI event: 47.5%(1052/2214) vs. 47.2%(1047/2218)
| Deaths: 1.7%(37/2214) vs. 1.8%(40/2218)
| Esophageal ulcer: 0.2%(4/2214) vs. 0.2%(4/2218)
| Esophagitis: 0.9%(19/2214) vs. 0.5%(10/2218)
| Other esophageal: 2.0%(44/2214) vs. 1.8%(41/2218)
Cummings SR et al., 2007 ^59^ | Alendronate vs Placebo:
| Any atrial-fibrillation adverse event: 2.5%(81/3236) vs 2.2%(71/3223)
| Serious atrial-fibrillation adverse event: 1.5%(47/3236) vs 1.0%(31/3223)
Curb JD et al., 2006 ^60^ | CEE vs. Placebo:
| DVT: 1.6%(85/5310) vs. 1.1%(59/5429)
| DVT & pulmonary embolism: 0.5%(26/5310) vs. 0.2%(12/5429)
| Non-procedure related DVT: 1.2%(64/5310) vs. 0.7%(37/5429)
| Non-procedure related PE: 0.6%(32/5310) vs. 0.5%(28/5429)
| Non-procedure related VT: 1.5%(78/5310) vs. 1.0%(54/5429)
| Procedure-related DVT: 0.3%(18/5310) vs. 0.4%(20/5429)
| Procedure-related PE: 0.3%(16/5310) vs. 0.2%(9/5429)
| Procedure-related VT: 0.5%(27/5310) vs. 0.5%(28/5429)
| Pulmonary embolism: 1.0%(52/5310) vs. 0.7%(39/5429)
| Venous thrombosis: 2.1%(111/5310) vs. 1.6%(86/5429)
Curtis JR et al., 2006 ^61^ | Alendronate vs. Risedronate:
| GI event: 23.3%(176/754) vs. 22.5%(91/404)
Cushman M et al., 2004 ^62^ | Estrogen,+Progesterone vs. Placebo:
| Non-procedure-related: deep vein thrombosis: 1.0%(87/8506) vs. 0.5%(40/8102)
| Non-procedure-related: pulmonary embolus: 0.8%(65/8506) vs. 0.3%(23/8102)
| Procedure-related: deep vein thrombosis: 0.3%(25/8506) vs. 0.2%(14/8102)
| Procedure-related: pulmonary embolus: 0.2%(16/8506) vs. 0.1%(12/8102)
D'Amelio P et al., 2003 ^63^ | Raloxifene vs. Raloxifene+Clodronate:
| Injection site pain: 0.0%(0/23) vs. 81.8%(18/22)
Deal C et al., 2005 ^64^ | Teriparatide + placebo vs. Teriparatide + raloxifene:
| Hot flushes: 4.4%(3/68) vs. 17.4%(12/69)
| Serious AE: 5.9%(4/68) vs. 5.8%(4/69)
| Vomiting: 7.4%(5/68) vs. 0.0%(0/69)
Decensi A et al., 2003 ^65^ | Control ER neg. vs. Control ER pos vs. Tamoxifen 1mg vs. Tamoxifen 20mg vs. Tamoxifen 5mg:
| Any AE: 0.0%(0/34) vs. 0.0%(0/29) vs. 22.5%(9/40) vs. 27.5%(11/40) vs. 30.0%(12/40)
| Death: 0.0%(0/34) vs. 0.0%(0/29) vs. 2.5%(1/40) vs. 0.0%(0/40) vs. 0.0%(0/40)
| Hot flashes: 0.0%(0/34) vs. 0.0%(0/29) vs. 32.0%(13/40) vs. 50.0%(20/40) vs. 36.0%(14/40)
| Metastasis at distant organ: 0.0%(0/34) vs. 0.0%(0/29) vs. 0.0%(0/40) vs. 2.5%(1/40) vs. 0.0%(0/40)
| Vaginal discharge: 0.0%(0/34) vs. 0.0%(0/29) vs. 26.0%(10/40) vs. 47.0%(19/40) vs. 22.0%(9/40)
Delmas PD et al., 1997 ^66^ | Raloxifene 150 mg vs. Raloxifene 60 mg vs. Placebo:
| Breast pain: 0.0%(0/147) vs. 3.3%(5/152) vs. 2.0%(3/150)
| Hot flashes: 0.0%(0/147) vs. 26.3%(40/152) vs. 22.7%(34/150)
| Vaginal bleeding: 0.0%(0/147) vs. 3.0%(4/152) vs. 2.2%(3/150)
Delmas PD et al., 1997 ^67^ | Risedronate+Tamoxifen vs. Tamoxifen+Placebo:
| Abdominal pain: 18.5%(5/27) vs. 7.7%(2/26)
| Bone pain & rash: 3.7%(1/27) vs. 0.0%(0/26)
| Deaths due to relapse of breast cancer: 3.7%(1/27) vs. 3.8%(1/26)
| Leukoneutropenia: 0.0%(0/27) vs. 3.8%(1/26)
| Liver function abnormality: 7.4%(2/27) vs. 0.0%(0/26)
| Relapse of breast cancer: 3.7%(1/27) vs. 11.5%(3/26)
| Serious adverse event: 37.0%(10/27) vs. 46.2%(12/26)
Devogelaer JP et al., 1996 ^68^ | Alendronate 10mg vs. Alendronate 20/5mg vs. Alendronate 5mg vs. Placebo:
| Serious AE: 6.9%(7/102) vs. 17.1%(18/105) vs. 13.5%(14/104) vs. 16.6%(34/205)
| Upper GI AE: 14.7%(15/102) vs. 18.1%(19/105) vs. 17.3%(18/104) vs. 17.1%(35/205)
Doran PM et al., 2001 ^69^ | Raloxifene vs. Placebo:
| Breast tenderness: 8.0%(2/25) vs. 12.0%(3/25)
| Decrease in erectile function: 8.0%(2/25) vs. 4.0%(1/25)
| Hot flushes: 16.0%(4/25) vs. 0.0%(0/25)
| Prostatic symptom: 8.0%(2/25) vs. 12.0%(3/25)
| Worsening libido: 12.0%(3/25) vs. 8.0%(2/25)
Downs RW et al., 1999 ^70^ | Alendronate 1 mg - alendronate 10 mg vs. Alendronate 2.5 mg - alendronate 10 mg vs. Alendronate 5 mg - alendronate 10 mg vs. Placebo - alendronate 10 mg:
| Death: 1.8%(1/57) vs. 1.6%(1/63) vs. 0.0%(0/63) vs. 0.0%(0/63)
| Drug-related AE: 1.8%(1/57) vs. 7.9%(5/63) vs. 6.3%(4/63) vs. 3.2%(2/63)
| Patients with one or more AEs: 80.7%(46/57) vs. 82.5%(52/63) vs. 79.4%(50/63) vs. 81.0%(51/63)
| Serious AE: 8.8%(5/57) vs. 12.7%(8/63) vs. 11.1%(7/63) vs. 12.7%(8/63)
| Serious GI affects: 0.0%(0/57) vs. 0.0%(0/63) vs. 0.0%(0/63) vs. 1.6%(1/63)
| Serious drug-related AE: 0.0%(0/57) vs. 0.0%(0/63) vs. 0.0%(0/63) vs. 0.0%(0/63)
| Upper GI AEs - drug-related: 1.8%(1/57) vs. 7.9%(5/63) vs. 4.8%(3/63) vs. 1.6%(1/63)
| Upper GI AEs - one or more: 7.0%(4/57) vs. 19.0%(12/63) vs. 9.5%(6/63) vs. 14.3%(9/63)
| Upper GI AEs - serious: 0.0%(0/57) vs. 0.0%(0/63) vs. 0.0%(0/63) vs. 1.6%(1/63)
| Upper GI AEs- serious drug-related: 0.0%(0/57) vs. 0.0%(0/63) vs. 0.0%(0/63) vs. 0.0%(0/63)
Downs RW et al., 2000 ^71^ | Alendronate vs. Calcitonin vs. Placebo:
| Abdominal distension: 1.7%(2/118) vs. 0.0%(0/123) vs. 3.4%(2/58)
| Abdominal pain: 4.2%(5/118) vs. 0.8%(1/123) vs. 1.7%(1/58)
| Acid regurgitation: 2.5%(3/118) vs. 0.0%(0/123) vs. 6.9%(4/58)
| Any serious AE: 5.9%(7/118) vs. 4.1%(5/123) vs. 3.4%(2/58)
| Chest pain: 2.5%(3/118) vs. 0.0%(0/123) vs. 3.4%(2/58)
| Constipation: 0.8%(1/118) vs. 1.6%(2/123) vs. 3.4%(2/58)
| Dyspepsia: 4.2%(5/118) vs. 0.0%(0/123) vs. 0.0%(0/58)
| Epistaxis: 0.0%(0/118) vs. 4.9%(6/123) vs. 0.0%(0/58)
| Flatulence: 0.8%(1/118) vs. 0.0%(0/123) vs. 3.4%(2/58)
| Nasal irritation: 0.0%(0/118) vs. 6.5%(8/123) vs. 0.0%(0/58)
| Nausea: 3.4%(4/118) vs. 0.8%(1/123) vs. 1.7%(1/58)
| Rhinitis: 0.0%(0/118) vs. 3.3%(4/123) vs. 0.0%(0/58)
Draper MW et al., 1996 ^72^ | Estrogen vs. Raloxifene 200 mg vs. Raloxifene 600 mg vs. Placebo:
| Back pain: 0.0%(0/64) vs. 1.7%(1/60) vs. 3.2%(2/63) vs. 10.9%(7/64)
| Breast pain: 15.6%(10/64) vs. 0.0%(0/60) vs. 1.6%(1/63) vs. 7.8%(5/64)
| Vaginitis: 12.5%(8/64) vs. 1.7%(1/60) vs. 4.8%(3/63) vs. 3.1%(2/64)
| Vasodilation: 3.1%(2/64) vs. 11.7%(7/60) vs. 22.2%(14/63) vs. 10.9%(7/64)
Eastell R et al., 2000 ^73^ | Risedronate 15 mg cyclical vs. Risedronate 2.5 mg/d vs. Placebo:
| AE: 22.5%(9/40) vs. 15.0%(6/40) vs. 15.0%(6/40)
| Abdominal pain: 20.0%(8/40) vs. 20.0%(8/40) vs. 2.5%(1/40)
| Duodenal ulcers: 5.0%(2/40) vs. 0.0%(0/40) vs. 0.0%(0/40)
| Dyspepsia: 30.0%(12/40) vs. 20.0%(8/40) vs. 42.5%(17/40)
| Esophagitis: 2.5%(1/40) vs. 5.0%(2/40) vs. 0.0%(0/40)
| Esophagitis with gastric and duodenal ulcers: 0.0%(0/40) vs. 2.5%(1/40) vs. 0.0%(0/40)
| Gastric erosion: 0.0%(0/40) vs. 0.0%(0/40) vs. 2.5%(1/40)
| Gastric ulcer and esophagitis: 0.0%(0/40) vs. 0.0%(0/40) vs. 2.5%(1/40)
| Gastric ulcers: 0.0%(0/40) vs. 0.0%(0/40) vs. 2.5%(1/40)
| Gastritis: 5.0%(2/40) vs. 0.0%(0/40) vs. 2.5%(1/40)
| Nausea: 12.5%(5/40) vs. 12.5%(5/40) vs. 7.5%(3/40)
| Serious AE: 47.5%(19/40) vs. 62.5%(25/40) vs. 52.5%(21/40)
| Upper GI AE: 52.5%(21/40) vs. 37.5%(15/40) vs. 55.0%(22/40)
Eisman JA et al., 2004 ^74^ | Alendronate vs. Placebo:
| Any adverse event: 40.4%(91/225) vs. 38.4%(86/224)
| Abdominal colic: 0.4%(1/225) vs. 0.4%(1/224)
| Abdominal pain: 0.9%(2/225) vs. 0.9%(2/224)
| Any drug-related* upper gastrointestinal adverse event: 8.0%(18/225) vs. 6.7%(15/224)
| Any serious upper gastrointestinal adverse event: 0.4%(1/225) vs. 0.4%(1/224)
| Any upper gastrointestinal adverse event: 9.3%(21/225) vs. 9.8%(22/224)
| Bloated feeling: 0.0%(0/225) vs. 0.9%(2/224)
| Dyspepsia: 0.9%(2/225) vs. 0.4%(1/224)
| Dysphagia: 0.0%(0/225) vs. 0.4%(1/224)
| Epigastric discomfort: 0.4%(1/225) vs. 0.0%(0/224)
| Epigastric pain: 1.8%(4/225) vs. 1.3%(3/224)
| Esophageal ulcer: 0.0%(0/225) vs. 0.4%(1/224)
| Gastritis: 0.0%(0/225) vs. 0.9%(2/224)
| Gastroenteritis: 0.4%(1/225) vs. 0.0%(0/224)
| Gastroesophageal reflux disease: 0.0%(0/225) vs. 0.4%(1/224)
| Heartburn: 2.7%(6/225) vs. 0.9%(2/224)
| Nausea: 3.6%(8/225) vs. 2.7%(6/224)
| Tympanism: 0.0%(0/225) vs. 0.4%(1/224)
| Vomiting: 1.3%(3/225) vs. 0.0%(0/224)
El-Agroudy AE et al., 2005 ^75^ | Alendronate vs. Calcitonin vs. Vitamin D vs. Control:
| Hypocalcemia: 20.0%(3/15) vs. 13.3%(2/15) vs. 0.0%(0/15) vs. 0.0%(0/15)
| Nasal stuffiness: 0.0%(0/15) vs. 13.3%(2/15) vs. 0.0%(0/15) vs. 0.0%(0/15)
| Nausea and epigastric pain: 13.3%(2/15) vs. 0.0%(0/15) vs. 0.0%(0/15) vs. 0.0%(0/15)
Ensrud K et al., 2006 ^76^ | Raloxifene vs. Placebo:
| Cardiovascular event: 5.5%(149/2725) vs. 4.7%(61/1286)
| Cardiovascular event - fatal: 0.6%(17/2725) vs. 0.5%(6/1286)
| Cardiovascular event - nonfatal: 5.0%(137/2725) vs. 4.4%(57/1286)
| Cerebrovascular event: 2.7%(73/2725) vs. 2.3%(29/1286)
| Cerebrovascular event - nonfatal: 2.6%(70/2725) vs. 2.3%(29/1286)
| Coronary event: 3.1%(85/2725) vs. 2.6%(33/1286)
| Coronary event - fatal: 0.4%(11/2725) vs. 0.4%(5/1286)
| Coronary event - nonfatal: 2.7%(74/2725) vs. 2.3%(29/1286)
| Fatal stroke: 0.2%(6/2725) vs. 0.1%(1/1286)
| Myocardial infarction: 1.2%(33/2725) vs. 0.9%(12/1286)
| Stroke: 1.8%(49/2725) vs. 1.5%(19/1286)
| Transient ischemic attack: 1.0%(26/2725) vs. 0.9%(12/1286)
| Unstable angina: 1.5%(42/2725) vs. 1.4%(18/1286)
Ensrud KE et al., 2004 ^77^ | Alendronate vs. Placebo:
| Abdominal pain: 5.0%(33/662) vs. 5.7%(25/437)
| Acid reflux: 3.3%(22/662) vs. 3.7%(16/437)
| Any AE resulting in hospitalization: 27.6%(183/662) vs. 28.6%(125/437)
| Any UGI tract event: 29.8%(197/662) vs. 35.7%(156/437)
| Deaths: 2.4%(16/662) vs. 1.8%(8/437)
| Duodenal ulcer: 0.5%(3/662) vs. 0.2%(1/437)
| Esophageal ulcer: 0.6%(4/662) vs. 0.5%(2/437)
| Esophagitis: 0.5%(3/662) vs. 0.7%(3/437)
| Gastric ulcer: 0.5%(3/662) vs. 0.9%(4/437)
Evans RA et al., 1993 ^78^ | Calcium vs. Etidronate vs. Etidronate+Phosphate:
| Constipation: 18.2%(2/11) vs. 6.7%(1/15) vs. 0.0%(0/10)
| Diarrhea: 0.0%(0/11) vs. 46.7%(7/15) vs. 50.0%(5/10)
| Dry mouth: 9.1%(1/11) vs. 0.0%(0/15) vs. 0.0%(0/10)
| Hip pain: 0.0%(0/11) vs. 6.7%(1/15) vs. 0.0%(0/10)
| Indigestion: 27.3%(3/11) vs. 0.0%(0/15) vs. 0.0%(0/10)
| Leg cramps: 0.0%(0/11) vs. 6.7%(1/15) vs. 0.0%(0/10)
| Mild nausea: 0.0%(0/11) vs. 46.7%(7/15) vs. 30.0%(3/10)
| Skin rash: 0.0%(0/11) vs. 6.7%(1/15) vs. 0.0%(0/10)
Evio S et al., 2004 ^79^ | Alendronate vs. Alendronate+Estrogen vs. Estrogen:
| Arrhythmia: 0.0%(0/30) vs. 3.3%(1/30) vs. 3.3%(1/30)
| Back and leg pains: 6.7%(2/30) vs. 0.0%(0/30) vs. 0.0%(0/30)
| Breast tenderness: 0.0%(0/30) vs. 0.0%(0/30) vs. 16.7%(5/30)
| Myocardial infarction: 3.3%(1/30) vs. 0.0%(0/30) vs. 0.0%(0/30)
| Repeated respiratory infections: 0.0%(0/30) vs. 3.3%(1/30) vs. 0.0%(0/30)
| Stomach problems: 6.7%(2/30) vs. 6.7%(2/30) vs. 6.7%(2/30)
| With night sweating: 0.0%(0/30) vs. 0.0%(0/30) vs. 3.3%(1/30)
Fan SL et al., 2003 ^80^ | Pamidronate vs. Control:
| Acute rejection: 55.6%(5/9) vs. 75.0%(6/8)
Finkelstein JS et al., 1998 ^81^ | GnRH vs. PTH+ GnRH:
| Acne: 13.6%(3/22) vs. 9.5%(2/21)
| Arthralgia: 31.8%(7/22) vs. 61.9%(13/21)
| Back pain: 13.6%(3/22) vs. 19.0%(4/21)
| Emotional lability: 40.9%(9/22) vs. 42.9%(9/21)
| Hair loss: 4.5%(1/22) vs. 9.5%(2/21)
| Headaches: 59.1%(13/22) vs. 66.7%(14/21)
| Mild discomfort at injection site: 0.0%(0/22) vs. 9.5%(2/21)
| Mild erythema at injection site: 0.0%(0/22) vs. 9.5%(2/21)
| Mild hypercalcemia at 24hrs after injection: 0.0%(0/22) vs. 1.0%(0/21)
| Mild hypercalcemia at 4hrs after injection: 0.0%(0/22) vs. 17.0%(4/21)
| Mild nausea: 4.5%(1/22) vs. 33.3%(7/21)
| Myalgias: 13.6%(3/22) vs. 19.0%(4/21)
| Nasal irritation: 31.8%(7/22) vs. 4.8%(1/21)
| Vaginal dryness: 22.7%(5/22) vs. 19.0%(4/21)
| Vasomotor flushes: 100.0%(22/22) vs. 95.2%(20/21)
| Weight gain > 5kg: 31.8%(7/22) vs. 33.3%(7/21)
| Weight loss > 5kg: 12.0%(3/22) vs. 12.0%(3/21)
Finkelstein JS et al., 2006 ^82^ | Alendronate & teriparatide vs. Teriparatide:
| Hypercalcemia - dose reduced: 14.3%(4/28) vs. 7.4%(2/27)
| Hypercalciuria - dose reduced: 7.1%(2/28) vs. 14.8%(4/27)
Fisher B et al., 1998 ^83^ | Tamoxifen 20mg vs. Placebo:
| Acute ischemic syndrome: 0.4%(27/6681) vs. 0.3%(20/6707)
| Amyotrophic lateral sclerosis resulting in death: 0.0%(0/6681) vs. 0.0%(2/6707)
| Angina requiring coronary artery bypass or angioplasty: 0.2%(13/6681) vs. 0.2%(14/6707)
| Automobile accident resulting in death: 0.0%(1/6681) vs. 0.0%(2/6707)
| Breast cancer: 1.9%(124/6681) vs. 3.6%(244/6707)
| Cancer death - primary site unknown: 0.0%(3/6681) vs. 0.1%(5/6707)
| Cataracts in people cataract-free at randomization: 8.6%(574/6681) vs. 7.6%(507/6707)
| Colon cancer: 0.2%(11/6681) vs. 0.1%(9/6707)
| Connective tissue cancer: 0.0%(1/6681) vs. 0.0%(2/6707)
| Death - Brain cancer: 0.0%(1/6681) vs. 0.0%(3/6707)
| Death - Breast cancer: 0.0%(3/6681) vs. 0.1%(6/6707)
| Death - Colon cancer: 0.0%(1/6681) vs. 0.0%(1/6707)
| Death - Extrahepatic bile duct cancer: 0.0%(0/6681) vs. 0.0%(1/6707)
| Death - Heart disease (ischemic and other): 0.2%(13/6681) vs. 0.2%(12/6707)
| Death - Kidney cancer: 0.0%(0/6681) vs. 0.0%(2/6707)
| Death - Lung cancer: 0.1%(8/6681) vs. 0.2%(11/6707)
| Death - Lymphatic system cancer: 0.0%(2/6681) vs. 0.1%(4/6707)
| Death - Melanoma cancer: 0.0%(1/6681) vs. 0.0%(0/6707)
| Death - Myocardial infarction: 0.1%(7/6681) vs. 0.1%(8/6707)
| Death - Occlusive stroke: 0.0%(0/6681) vs. 0.0%(2/6707)
| Death - Ovary cancer: 0.0%(2/6681) vs. 0.0%(1/6707)
| Death - Pancreas cancer: 0.0%(2/6681) vs. 0.1%(6/6707)
| Death - Pulmonary embolus: 0.0%(3/6681) vs. 0.0%(0/6707)
| Death - Stroke: 0.1%(4/6681) vs. 0.0%(3/6707)
| Death - Thyroid gland cancer: 0.0%(0/6681) vs. 0.0%(1/6707)
| Death - Unknown cause: 0.1%(4/6681) vs. 0.1%(4/6707)
| Death - Uterus (endometrium) cancer: 0.0%(0/6681) vs. 0.0%(1/6707)
| Death - arterial disease other than stroke: 0.0%(2/6681) vs. 0.0%(0/6707)
| Death - vascular disease: 0.3%(22/6681) vs. 0.2%(15/6707)
| Deep vein thrombosis: 0.5%(35/6681) vs. 0.3%(22/6707)
| Depression Center for Epidemiological Studies Depression Scale (ces-d) 0–15: 65.4%(4369/6681) vs. 65.4%(4386/6707)
| Depression ces-d 16–22: 15.6%(1042/6681) vs. 16.1%(1080/6707)
| Depression ces-d 23–29: 10.1%(675/6681) vs. 9.5%(637/6707)
| Depression ces-d 30–36: 5.1%(341/6681) vs. 5.4%(362/6707)
| Depression ces-d >=37: 3.7%(247/6681) vs. 3.6%(241/6707)
| Gallbladder cancer: 0.0%(0/6681) vs. 0.0%(1/6707)
| Hemorrhagic stroke: 0.1%(10/6681) vs. 0.1%(6/6707)
| Hemorrhagic stroke - death: 0.0%(3/6681) vs. 0.0%(1/6707)
| Hot flashes - extremely bothersome: 17.6%(1176/6681) vs. 10.1%(677/6707)
| Hot flashes - moderately bothersome: 21.8%(1456/6681) vs. 21.7%(1455/6707)
| Hot flashes - not bothersome: 19.4%(1296/6681) vs. 31.4%(2106/6707)
| Hot flashes - quite a bit bothersome: 28.1%(1877/6681) vs. 18.6%(1248/6707)
| Hot flashes - slightly bothersome: 14.1%(942/6681) vs. 18.2%(1221/6707)
| In situ endometrial cancer: 0.0%(1/6681) vs. 0.0%(3/6707)
| Invasive breast cancer: 1.3%(89/6681) vs. 2.6%(175/6707)
| Invasive endometrial cancer: 0.5%(36/6681) vs. 0.2%(15/6707)
| Kidney cancer: 0.0%(2/6681) vs. 0.0%(3/6707)
| Liver cancer: 0.0%(0/6681) vs. 0.0%(0/6707)
| Lung, trachea, bronchus cancer: 0.3%(20/6681) vs. 0.3%(17/6707)
| Lymphatic, hematopoietic systems cancer: 0.2%(14/6681) vs. 0.2%(11/6707)
| Miscellaneous deaths (11 different causes): 0.1%(7/6681) vs. 0.1%(6/6707)
| Mouth, pharynx, larynx cancer: 0.0%(3/6681) vs. 0.0%(2/6707)
| Myocardial infarction: 0.5%(31/6681) vs. 0.4%(28/6707)
| Nervous system cancer: 0.0%(1/6681) vs. 0.0%(3/6707)
| Noninvasive breast cancer: 0.5%(35/6681) vs. 1.0%(69/6707)
| Occlusive stroke: 0.3%(21/6681) vs. 0.2%(14/6707)
| Other genital cancer: 0.1%(4/6681) vs. 0.1%(4/6707)
| Ovary/fallopian tube cancer: 0.1%(10/6681) vs. 0.2%(11/6707)
| Pancreas cancer: 0.1%(4/6681) vs. 0.1%(7/6707)
| Pulmonary embolism: 0.3%(18/6681) vs. 0.1%(6/6707)
| Rectum cancer: 0.1%(4/6681) vs. 0.0%(3/6707)
| Retroperitoneum cancer: 0.0%(0/6681) vs. 0.0%(1/6707)
| Skin cancer: 0.2%(11/6681) vs. 0.1%(9/6707)
| Stomach cancer: 0.0%(1/6681) vs. 0.0%(2/6707)
| Stroke of unknown etiology: 0.1%(7/6681) vs. 0.1%(4/6707)
| Thyroid gland cancer: 0.1%(4/6681) vs. 0.1%(5/6707)
| Transient ischemic attach: 0.3%(19/6681) vs. 0.4%(25/6707)
| Unknown cancer: 0.1%(4/6681) vs. 0.1%(6/6707)
| Urinary bladder cancer: 0.0%(3/6681) vs. 0.0%(1/6707)
| Vaginal discharge - extremely bothersome: 3.1%(207/6681) vs. 1.2%(80/6707)
| Vaginal discharge - moderately bothersome: 16.6%(1109/6681) vs. 8.5%(570/6707)
| Vaginal discharge - quite a bit bothersome: 9.3%(621/6681) vs. 3.3%(221/6707)
| Vaginal discharge - slightly bothersome: 26.2%(1750/6681) vs. 21.8%(1462/6707)
Flicker L et al., 1997 ^84^ | Calcitonin vs. Calcitonin+Nandrolone vs. Nandrolone vs. Placebo:
| Death: 6.3%(2/32) vs. 3.2%(1/31) vs. 3.3%(1/30) vs. 3.3%(1/30)
| Erythematous vocal cords: 0.0%(0/32) vs. 3.2%(1/31) vs. 0.0%(0/30) vs. 0.0%(0/30)
| Increased facial hair: 0.0%(0/32) vs. 0.0%(0/31) vs. 20.0%(6/30) vs. 0.0%(0/30)
| Leg edema: 0.0%(0/32) vs. 0.0%(0/31) vs. 13.3%(4/30) vs. 0.0%(0/30)
| Nasal irritation: 0.0%(0/32) vs. 0.0%(0/31) vs. 0.0%(0/30) vs. 3.3%(1/30)
| Voice hoarseness: 0.0%(0/32) vs. 0.0%(0/31) vs. 83.3%(25/30) vs. 0.0%(0/30)
Fogelman I et al., 2000 ^85^ | Etidronate vs. Placebo:
| Lung cancer: 0.0%(0/59) vs. 1.6%(1/62)
Fogelman I et al., 2000 ^86^ | Risedronate 2.5mg vs. Risedronate 5mg vs. Placebo:
| Any clinical event: 93.5%(172/184) vs. 94.4%(169/179) vs. 95.6%(172/180)
| Abdominal pain: 10.9%(20/184) vs. 12.8%(23/179) vs. 12.2%(22/180)
| Dyspepsia: 13.6%(25/184) vs. 8.4%(15/179) vs. 10.0%(18/180)
| Esophageal ulcer: 1.1%(2/184) vs. 1.7%(3/179) vs. 0.6%(1/180)
| Esophagitis: 3.3%(6/184) vs. 1.7%(3/179) vs. 2.2%(4/180)
| Gastritis: 1.1%(2/184) vs. 1.7%(3/179) vs. 0.0%(0/180)
| Serious AE: 11.4%(21/184) vs. 14.5%(26/179) vs. 15.0%(27/180)
| Stomach ulcer: 1.1%(2/184) vs. 0.6%(1/179) vs. 2.8%(5/180)
| Withdrawal due to AE: 9.8%(18/184) vs. 10.6%(19/179) vs. 7.8%(14/180)
Frediani B et al., 1998 ^87^ | Alendronate vs. Alendronate, Vitamin D vs. Vitamin D vs. Placebo:
| Gastric pain: 6.7%(2/30) vs. 10.0%(3/30) vs. 0.0%(0/30) vs. 26.7%(8/30)
Freedman M et al., 2001 ^88^ | Estrogen vs. Raloxifene 150 mg vs. Raloxifene 60 mg vs. Placebo:
| Breast pain: 14.5%(8/55) vs. 6.7%(4/60) vs. 3.3%(2/61) vs. 6.8%(4/59)
Fujita T et al., 1999 ^89^ | PTH 100 u vs. PTH 200 u vs. PTH 50 u:
| Abdominal pain: 0.0%(0/75) vs. 1.4%(1/72) vs. 1.4%(1/73)
| Anorexia: 0.0%(0/75) vs. 1.4%(1/72) vs. 0.0%(0/73)
| Belching: 1.3%(1/75) vs. 0.0%(0/72) vs. 0.0%(0/73)
| Chills: 0.0%(0/75) vs. 1.4%(1/72) vs. 0.0%(0/73)
| Dizziness: 2.7%(2/75) vs. 1.4%(1/72) vs. 1.4%(1/73)
| Eczema: 0.0%(0/75) vs. 0.0%(0/72) vs. 1.4%(1/73)
| Facial flush: 0.0%(0/75) vs. 1.4%(1/72) vs. 0.0%(0/73)
| Febrile episode: 1.3%(1/75) vs. 4.2%(3/72) vs. 0.0%(0/73)
| Febrile sensation: 2.7%(2/75) vs. 1.4%(1/72) vs. 1.4%(1/73)
| General malaise: 1.3%(1/75) vs. 4.2%(3/72) vs. 1.4%(1/73)
| Headache: 4.0%(3/75) vs. 5.6%(4/72) vs. 2.7%(2/73)
| Itching: 0.0%(0/75) vs. 0.0%(0/72) vs. 1.4%(1/73)
| Lumbago: 1.3%(1/75) vs. 1.4%(1/72) vs. 0.0%(0/73)
| Nausea: 9.3%(7/75) vs. 20.8%(15/72) vs. 5.5%(4/73)
| Sensation of weakness: 1.3%(1/75) vs. 1.4%(1/72) vs. 0.0%(0/73)
| Sleepiness: 1.3%(1/75) vs. 0.0%(0/72) vs. 0.0%(0/73)
| Subcutaneous hemorrhage: 0.0%(0/75) vs. 0.0%(0/72) vs. 1.4%(1/73)
| Thirst: 0.0%(0/75) vs. 0.0%(0/72) vs. 1.4%(1/73)
| Vomiting: 1.3%(1/75) vs. 5.6%(4/72) vs. 0.0%(0/73)
| Whole-body reddening: 1.3%(1/75) vs. 0.0%(0/72) vs. 0.0%(0/73)
| Yawning: 1.3%(1/75) vs. 0.0%(0/72) vs. 0.0%(0/73)
Fukunaga M et al., 2002 ^90^ | Etidronate vs. Risedronate:
| Any AE: 81.2%(95/117) vs. 81.4%(96/118)
| Abdominal distension: 1.7%(2/117) vs. 5.9%(7/118)
| Abnormal lab data: 12.0%(14/117) vs. 9.3%(11/118)
| Cardiovascular events: 0.9%(1/117) vs. 2.5%(3/118)
| Constipation: 6.0%(7/117) vs. 3.4%(4/118)
| Dermatologic events: 2.6%(3/117) vs. 2.5%(3/118)
| Epigastric pain: 7.7%(9/117) vs. 7.6%(9/118)
| GI events**: 19.7%(23/117) vs. 22.9%(27/118)
| Nausea: 0.9%(1/117) vs. 3.4%(4/118)
| Neurologic events: 4.3%(5/117) vs. 4.2%(5/118)
Fuleihan G et al., 2005 ^91^ | Pamidronate vs. Placebo:
| Amenorrheic: 52.4%(11/21) vs. 57.9%(11/19)
| Flu-like syndrome after first infusion: 4.8%(1/21) vs. 0.0%(0/19)
| Hypocalcemia: 0.0%(0/21) vs. 0.0%(0/19)
Geusens P et al., 1997 ^92^ | Etidronate vs. Placebo:
| Anaphylactic shock: 0.0%(0/18) vs. 5.3%(1/19)
| Death: 5.6%(1/18) vs. 0.0%(0/19)
| Diarrhea: 0.0%(0/18) vs. 10.5%(2/19)
| Nausea: 11.1%(2/18) vs. 5.3%(1/19)
| Vomiting: 5.6%(1/18) vs. 5.3%(1/19)
Geusens P et al., 1998 ^93^ | Etidronate vs. Placebo:
| Anaphylactic shock: 0.0%(0/18) vs. 5.3%(1/19)
| Death - Ruptured aortic aneurysm: 5.6%(1/18) vs. 0.0%(0/19)
| Diarrhea: 0.0%(0/18) vs. 10.5%(2/19)
| Nausea: 11.1%(2/18) vs. 5.3%(1/19)
| Vomiting: 5.6%(1/18) vs. 5.3%(1/19)
Giannini S et al., 2001 ^94^ | Alendronate+ Calcium+Vitamin D vs. Calcium+Vitamin D:
| Abdominal pain: 5.0%(1/20) vs. 15.0%(3/20)
| Acid regurgitation: 5.0%(1/20) vs. 0.0%(0/20)
| Nausea: 10.0%(2/20) vs. 5.0%(1/20)
Gnudi S et al., 1988 ^95^ | Calcitonin 100iu vs. Calcitonin 50iu vs. Placebo:
| Cutaneous rush: 0.0%(12/23) vs. 0.0%(12/22) vs. 0.0%(0/17)
| Gastrointestinal: 0.0%(25/23) vs. 0.0%(18/22) vs. 0.0%(6/17)
| Local pain: 0.0%(1/23) vs. 0.0%(0/22) vs. 0.0%(0/17)
| Vasomotor: 0.0%(31/23) vs. 0.0%(27/22) vs. 0.0%(0/17)
Golden NH et al., 2005 ^96^ | Alendronate vs. Placebo:
| Dyspepsia: 0.0%(0/15) vs. 5.9%(1/17)
| Nausea and abdominal bloating: 13.3%(2/15) vs. 11.8%(2/17)
Grady D et al., 2004 ^97^ | Raloxifene vs. Placebo:
| Any venous thrombosis: 1.2%(59/5129) vs. 0.5%(14/2576)
| Any venous thrombosis year 1: 0.5%(24/5129) vs. 0.1%(2/2576)
| Any venous thrombosis year 2: 0.3%(13/5129) vs. 0.0%(1/2576)
| Any venous thrombosis year 3: 0.3%(13/5129) vs. 0.3%(7/2576)
| Any venous thrombosis year 4: 0.2%(9/5129) vs. 0.2%(4/2576)
| Breast cancer: 0.0%(1/5129) vs. 0.0%(0/2576)
| Cancer: 0.2%(9/5129) vs. 0.2%(5/2576)
| Cataracts new: 4.6%(235/5129) vs. 4.9%(127/2576)
| Cataracts requiring surgery: 3.2%(163/5129) vs. 3.3%(86/2576)
| Cataracts total: 5.7%(291/5129) vs. 6.2%(160/2576)
| Cataracts worsening: 1.1%(56/5129) vs. 1.3%(33/2576)
| Death from gastrointestinal carcinoma: 0.0%(2/5129) vs. 0.0%(0/2576)
| Death from lung cancer: 0.0%(1/5129) vs. 0.0%(0/2576)
| Death from myocardial infarction: 0.0%(1/5129) vs. 0.0%(0/2576)
| Death from pulmonary embolism due to breast cancer: 0.1%(5/5129) vs. 0.0%(0/2576)
| Deep vein thrombosis: 0.8%(43/5129) vs. 0.3%(7/2576)
| Gallbladder disease new: 2.4%(121/5129) vs. 2.4%(63/2576)
| Gallbladder disease requiring surgery: 1.4%(71/5129) vs. 1.0%(25/2576)
| Gallbladder disease total: 2.5%(130/5129) vs. 2.6%(66/2576)
| Gallbladder disease worsening: 0.2%(9/5129) vs. 0.1%(3/2576)
| Idiopathic thromboembolic event: 0.3%(15/5129) vs. 0.0%(1/2576)
| Pulmonary embolism: 0.4%(18/5129) vs. 0.1%(2/2576)
| Retinal vein thrombosis: 0.1%(4/5129) vs. 0.2%(5/2576)
| Secondary thromboembolic event: 0.9%(44/5129) vs. 0.5%(13/2576)
| Uterine any hyperplasia: 0.2%(8/5129) vs. 0.1%(3/2576)
| Uterine cancer - homologous mixed mullerian tumor: 0.0%(0/5129) vs. 0.0%(1/2576)
| Uterine cancer - sarcoma: 0.0%(1/5129) vs. 0.0%(0/2576)
| Uterine complex hyperplasia: 0.0%(2/5129) vs. 0.0%(1/2576)
| Uterine not specified: 0.1%(3/5129) vs. 0.0%(0/2576)
| Uterine simple hyperplasia: 0.1%(3/5129) vs. 0.1%(2/2576)
Greenspan S et al., 2002 ^98^ | Alendronate vs. Placebo:
| Abdominal distension: 0.4%(1/224) vs. 0.4%(1/226)
| Abdominal pain: 3.1%(7/224) vs. 3.5%(8/226)
| Anorexia: 0.0%(0/224) vs. 0.4%(1/226)
| Digestive gas symptoms: 0.0%(0/224) vs. 0.4%(1/226)
| Duodenal ulcer: 0.4%(1/224) vs. 0.0%(0/226)
| Dyspepsia: 1.8%(4/224) vs. 2.7%(6/226)
| Epigastric discomfort: 0.9%(2/224) vs. 0.4%(1/226)
| GI disorder: 0.4%(1/224) vs. 0.0%(0/226)
| Gastritis: 0.4%(1/224) vs. 0.0%(0/226)
| GERD: 1.3%(3/224) vs. 0.4%(1/226)
| Heartburn: 2.2%(5/224) vs. 1.8%(4/226)
| Nausea: 1.8%(4/224) vs. 5.8%(13/226)
| Serious AE not drug related: 2.7%(6/224) vs. 1.8%(4/226)
| Vomiting: 1.3%(3/224) vs. 0.9%(2/226)
Greenspan SL et al., 1998 ^99^ | Alendronate vs. Placebo:
| GI complaints: 43.0%(26/60) vs. 47.0%(28/60)
Greenspan SL et al., 2003 ^100^ | Alendronate vs. Alendronate+Estrogen vs. Estrogen vs. Placebo:
| Bloating: 4.3%(4/93) vs. 5.3%(5/94) vs. 9.7%(9/93) vs. 2.2%(2/93)
| Breast tenderness: 23.7%(22/93) vs. 53.2%(50/94) vs. 55.9%(52/93) vs. 17.2%(16/93)
| Chest pain: 17.2%(16/93) vs. 9.6%(9/94) vs. 10.8%(10/93) vs. 14.0%(13/93)
| Deep venous thrombosis: 1.1%(1/93) vs. 0.0%(0/94) vs. 2.2%(2/93) vs. 0.0%(0/93)
| Dysphagia: 3.2%(3/93) vs. 2.1%(2/94) vs. 1.1%(1/93) vs. 2.2%(2/93)
| Endometrial biopsy: 2.2%(2/93) vs. 11.7%(11/94) vs. 12.9%(12/93) vs. 1.1%(1/93)
| Esophagitis: 28.0%(26/93) vs. 21.3%(20/94) vs. 18.3%(17/93) vs. 22.6%(21/93)
| Falls: 55.9%(52/93) vs. 52.1%(49/94) vs. 47.3%(44/93) vs. 45.2%(42/93)
| Heartburn: 18.3%(17/93) vs. 17.0%(16/94) vs. 11.8%(11/93) vs. 16.1%(15/93)
| High blood pressure: 5.4%(5/93) vs. 2.1%(2/94) vs. 6.5%(6/93) vs. 3.2%(3/93)
| Hospitalization: 36.6%(34/93) vs. 34.0%(32/94) vs. 43.0%(40/93) vs. 28.0%(26/93)
| Indigestion: 6.5%(6/93) vs. 1.1%(1/94) vs. 5.4%(5/93) vs. 4.3%(4/93)
| Menstrual cramps: 0.0%(0/93) vs. 5.3%(5/94) vs. 6.5%(6/93) vs. 0.0%(0/93)
| Menstrual spotting: 7.5%(7/93) vs. 33.0%(31/94) vs. 31.2%(29/93) vs. 9.7%(9/93)
| Myocardial infarction: 2.2%(2/93) vs. 1.1%(1/94) vs. 0.0%(0/93) vs. 1.1%(1/93)
| Peripheral edema: 9.7%(9/93) vs. 11.7%(11/94) vs. 14.0%(13/93) vs. 12.9%(12/93)
| Weight gain: 6.5%(6/93) vs. 8.5%(8/94) vs. 8.6%(8/93) vs. 8.6%(8/93)
Greenwald MW et al., 2005 ^101^ | Estrogen 0.25 mg vs. Estrogen 0.5 mg vs. Estrogen 1 mg vs. Estrogen 1 mg & NETA 0.25 mg vs. Estrogen 1 mg & NETA 0.5 mg vs. Estrogen 2 mg & NETA 1 mg vs. Placebo:
| Endometrial hyperplasia: 0.0%(0/45) vs. 2.3%(1/44) vs. 19.6%(9/46) vs. 0.0%(0/49) vs. 0.0%(0/47) vs. 0.0%(0/48) vs. 2.1%(1/48)
| Serious AE: 0.0%(0/45) vs. 0.0%(0/44) vs. 0.0%(0/46) vs. 0.0%(0/49) vs. 0.0%(0/47) vs. 0.0%(0/48) vs. 0.0%(0/48)
Grey AB et al., 1995 ^102^ | Tamoxifen vs. Placebo:
| Exacerbation of dyspepsia: 4.3%(1/23) vs. 0.0%(0/23)
| Hepatocellular carcinoma: 0.0%(0/23) vs. 4.3%(1/23)
| Severe flush: 4.3%(1/23) vs. 0.0%(0/23)
| Skin rash: 4.3%(1/23) vs. 0.0%(0/23)
| Vaginal discharge: 33.0%(33/23) vs. 0.0%(0/23)
| Vasomotor flushes: 52.2%(12/23) vs. 17.4%(4/23)
| Varicose eczema: 0.0%(0/23) vs. 4.3%(1/23)
| Xerostomia: 0.0%(0/23) vs. 4.3%(1/23)
Grotz W et al., 2001 ^103^ | Ibandronate vs. Placebo:
| Bone pain, flatulence: 7.5%(3/40) vs. 0.0%(0/40)
| Death: 5.0%(2/40) vs. 7.5%(3/40)
Grotz WH et al., 1998 ^104^ | Calcitonin vs. Clodronate vs. Control:
| Abdominal discomfort: 0.0%(0/16) vs. 6.7%(1/15) vs. 0.0%(0/15)
| Arthralgia: 6.3%(1/16) vs. 0.0%(0/15) vs. 0.0%(0/15)
| Coronary heart disease - death: 0.0%(0/16) vs. 0.0%(0/15) vs. 6.7%(1/15)
| Diarrhea: 0.0%(0/16) vs. 6.7%(1/15) vs. 0.0%(0/15)
| Heat sensation: 6.3%(1/16) vs. 0.0%(0/15) vs. 0.0%(0/15)
| Skin rash: 6.3%(1/16) vs. 0.0%(0/15) vs. 0.0%(0/15)
| Vomiting: 0.0%(0/16) vs. 0.0%(0/15) vs. 6.7%(1/15)
Gruber HE et al., 1984 ^105^ | Calcitonin vs. Control:
| Bedridden - cause not presented: 0.0%(0/24) vs. 4.8%(1/21)
| Eschar of 1 month at injection site: 4.2%(1/24) vs. 0.0%(0/21)
| Flushing and local inflammatory reaction at injection site: 8.3%(2/24) vs. 0.0%(0/21)
| Hot flashes: 0.0%(0/24) vs. 4.8%(1/21)
| Redness, tender, itching: 45.8%(11/24) vs. 0.0%(0/21)
Guanabens N et al., 2000 ^106^ | Etidronate vs. Fluoride:
| Death - unrelated to treatment: 1.6%(1/63) vs. 0.0%(0/55)
| Gastrointestinal symptoms: 15.9%(10/63) vs. 21.8%(12/55)
| Intercurrent illness: 3.2%(2/63) vs. 1.8%(1/55)
| Lower extremity pain syndrome: 0.0%(0/63) vs. 12.7%(7/55)
Guanabens N et al., 2003 ^107^ | Alendronate vs. Etidronate:
| Death - Liver failure: 0.0%(0/16) vs. 6.3%(1/16)
| GI symptoms: 6.3%(1/16) vs. 12.5%(2/16)
| Minor gastric symptoms: 12.5%(2/16) vs. 6.3%(1/16)
Guaraldi G et al., 2004 ^108^ | Alendronate+ Calcium, Vitamin D vs. Calcium, Vitamin D:
| Adverse gastrointestinal effects: 10.0%(2/18) vs. 10.0%(2/23)
Gurlek A et al., 1997 ^109^ | Calcitonin+Vitamin D vs. Etidronate+Vitamin D vs. Vitamin D:
| Hypercalcemia: 50.0%(5/10) vs. 40.0%(4/10) vs. 40.0%(4/10)
| Hypercalciuria: 70.0%(7/10) vs. 90.0%(9/10) vs. 100.0%(10/10)
| Renal stone: 0.0%(0/10) vs. 0.0%(0/10) vs. 10.0%(1/10)
Gutteridge DH et al., 2002 ^110^ | Calcium+Vitamin D vs. Calcium+Vitamin D+Fluoride vs. Estrogen+Calcium+Vitamin D vs. Estrogen+Calcium+Vitamin D+Fluoride:
| Aseptic necrosis of the left medial femoral condyle: 3.2%(1/31) vs. 0.0%(0/34) vs. 0.0%(0/17) vs. 0.0%(0/17)
Haderslev KV et al., 2000 ^111^ | Alendronate vs. Placebo:
| Any adverse effect: 80.0%(12/15) vs. 76.5%(13/17)
| Abdominal pain: 13.3%(2/15) vs. 11.8%(2/17)
| Any serious adverse effect: 33.3%(5/15) vs. 29.4%(5/17)
| Any upper gastrointestinal adverse effects (including dyspepsia, dysphagia: 26.7%(4/15) vs. 5.9%(1/17)
| Diarrhea: 20.0%(3/15) vs. 35.3%(6/17)
| Gaseous distention: 13.3%(2/15) vs. 17.6%(3/17)
Harris ST et al., 1993 ^112^ | Alendronate 20mg vs. Alendronate 40mg vs. Alendronate 5mg vs. Placebo:
| Abdominal pain: 12.5%(2/16) vs. 0.0%(0/16) vs. 6.3%(1/16) vs. 17.6%(3/17)
| Constipation: 6.3%(1/16) vs. 0.0%(0/16) vs. 0.0%(0/16) vs. 5.9%(1/17)
| Diarrhea: 6.3%(1/16) vs. 6.3%(1/16) vs. 6.3%(1/16) vs. 5.9%(1/17)
| Dyspepsia: 0.0%(0/16) vs. 12.5%(2/16) vs. 12.5%(2/16) vs. 5.9%(1/17)
| Nausea or vomiting: 12.5%(2/16) vs. 12.5%(2/16) vs. 18.8%(3/16) vs. 5.9%(1/17)
Harris ST et al., 1999 ^113^ | Risedronate vs. Placebo:
| Any clinical event: 96.6%(785/813) vs. 95.0%(774/815)
| Abdominal pain: 12.7%(103/813) vs. 11.9%(97/815)
| Any UGI tract event: 30.1%(245/813) vs. 26.9%(219/815)
| Drug related AE: 33.6%(273/813) vs. 29.0%(236/815)
| Duodenal ulcer: 0.1%(1/813) vs. 0.4%(3/815)
| Duodenitis: 1.1%(9/813) vs. 0.2%(2/815)
| Dyspepsia: 12.9%(105/813) vs. 11.3%(92/815)
| Esophagitis: 1.4%(11/813) vs. 1.6%(13/815)
| Gastritis: 3.8%(31/813) vs. 2.8%(23/815)
| Mod-severe UGI tract event: 13.0%(106/813) vs. 12.5%(102/815)
| Serious AE: 29.2%(237/813) vs. 26.9%(219/815)
Harris ST et al., 2001 ^114^ | Estrogen+Placebo vs. Estrogen+Risedronate:
| Abdominal pain: 1.5%(4/261) vs. 0.8%(2/263)
| All upper gastrointestinal (GI) AEs: 16.5%(43/261) vs. 16.3%(43/263)
| Asthenia: 1.5%(4/261) vs. 0.0%(0/263)
| Breast fibrocyst: 13.4%(35/261) vs. 8.7%(23/263)
| Breast pain: 30.3%(79/261) vs. 27.4%(72/263)
| Constipation: 1.9%(5/261) vs. 6.5%(17/263)
| Diarrhea: 4.2%(11/261) vs. 7.6%(20/263)
| Dyspepsia: 0.4%(1/261) vs. 0.8%(2/263)
| Esophagitis: 0.8%(2/261) vs. 0.4%(1/263)
| Gastric or duodenal ulcer: 1.1%(3/261) vs. 0.0%(0/263)
| Gastric ulcer with hemorrhage: 0.4%(1/261) vs. 0.0%(0/263)
| Gastritis: 0.8%(2/261) vs. 1.5%(4/263)
| Headache: 0.0%(0/261) vs. 0.8%(2/263)
| Hypertension: 5.7%(15/261) vs. 2.7%(7/263)
| Metrorrhagia: 1.5%(4/261) vs. 0.0%(0/263)
| Moderate to severe upper GI AEs: 8.0%(21/261) vs. 6.8%(18/263)
| Nausea: 1.5%(4/261) vs. 0.0%(0/263)
| Peptic ulcer: 0.0%(0/261) vs. 0.4%(1/263)
| Serious AEs: 8.8%(23/261) vs. 5.3%(14/263)
| Vaginal hemorrhage: 13.4%(35/261) vs. 8.7%(23/263)
Harris ST et al., 2004 ^115^ | Risedronate 35 mg once a week vs. Risedronate 50mg once a week vs. Risedronate 5mg daily:
| AE: 95.1%(461/485) vs. 94.7%(465/491) vs. 94.8%(455/480)
| Any upper GI AE: 25.6%(124/485) vs. 24.8%(122/491) vs. 22.7%(109/480)
| Moderate to severe upper GI AE: 7.2%(35/485) vs. 6.9%(34/491) vs. 8.8%(42/480)
| Serious AE: 13.2%(64/485) vs. 16.1%(79/491) vs. 14.0%(67/480)
Hasling C et al., 1994 ^116^ | Calcium vs. Estrogen+Progesterone vs. Etidronate vs. Etidronate+Triiodothyronine:
| Breast swelling: 0.0%(0/17) vs. 30.0%(6/20) vs. 0.0%(0/19) vs. 0.0%(0/18)
| Breast tenderness: 0.0%(0/17) vs. 10.0%(2/20) vs. 0.0%(0/19) vs. 0.0%(0/18)
| Constipation: 5.9%(1/17) vs. 0.0%(0/20) vs. 0.0%(0/19) vs. 0.0%(0/18)
| Could not bear regular periods: 0.0%(0/17) vs. 10.0%(2/20) vs. 0.0%(0/19) vs. 0.0%(0/18)
| Diarrhea: 0.0%(0/17) vs. 0.0%(0/20) vs. 5.3%(1/19) vs. 0.0%(0/18)
| Fatigue and dizziness: 0.0%(0/17) vs. 0.0%(0/20) vs. 0.0%(0/19) vs. 5.6%(1/18)
| Headache or fatigue: 0.0%(0/17) vs. 0.0%(0/20) vs. 0.0%(0/19) vs. 16.7%(3/18)
| Hypercalcemia: 11.8%(2/17) vs. 0.0%(0/20) vs. 0.0%(0/19) vs. 0.0%(0/18)
| Monthly menstrual bleeding did not return: 0.0%(0/17) vs. 5.0%(1/20) vs. 0.0%(0/19) vs. 0.0%(0/18)
| Slight headache or fatigue: 5.9%(1/17) vs. 0.0%(0/20) vs. 0.0%(0/19) vs. 16.7%(3/18)
| Tachycardia and fatigue: 0.0%(0/17) vs. 0.0%(0/20) vs. 0.0%(0/19) vs. 5.6%(1/18)
Haworth CS et al., 2001 ^117^ | Pamidronate vs. Control:
| Death - respiratory failure: 6.7%(1/15) vs. 6.3%(1/16)
| Moderate to severe bone pain after first dose: 73.3%(11/15) vs. 0.0%(0/16)
Hay JE et al., 2001 ^118^ | Calcitonin vs. Placebo:
| Death: 3.4%(1/29) vs. 0.0%(0/34)
| Transient diarrhea: 3.4%(1/29) vs. 0.0%(0/34)
Heath DA et al., 2000 ^119^ | Etidronate vs. Control:
| Back pain: 2.6%(1/38) vs. 7.7%(3/39)
| Breast abscess: 0.0%(0/38) vs. 2.6%(1/39)
| Colitis: 2.6%(1/38) vs. 0.0%(0/39)
| Dyspepsia: 18.4%(7/38) vs. 0.0%(0/39)
| Malignant breast tumor: 2.6%(1/38) vs. 0.0%(0/39)
| Malignant eye cyst: 2.6%(1/38) vs. 0.0%(0/39)
| Nausea: 10.5%(4/38) vs. 2.6%(1/39)
| Report adverse effect: 76.3%(29/38) vs. 51.3%(20/39)
| Serious adverse effect: 7.9%(3/38) vs. 2.6%(1/39)
Henderson S et al., 2006 ^120^ | Risedronate vs. Placebo:
| Abdominal pain: 6.7%(2/30) vs. 9.7%(3/31)
| Arthralgia: 20.0%(6/30) vs. 25.8%(8/31)
| Bowel obstruction: 3.3%(1/30) vs. 0.0%(0/31)
| Constipation: 6.7%(2/30) vs. 0.0%(0/31)
| Diarrhea: 40.0%(12/30) vs. 54.8%(17/31)
| Dizziness: 6.7%(2/30) vs. 3.2%(1/31)
| Flu-like symptoms: 16.7%(5/30) vs. 12.9%(4/31)
| Headache: 6.7%(2/30) vs. 3.2%(1/31)
| Nausea / vomiting: 6.7%(2/30) vs. 12.9%(4/31)
| Palpitations: 0.0%(0/30) vs. 3.2%(1/31)
| Pruritus: 6.7%(2/30) vs. 3.2%(1/31)
| Rash: 3.3%(1/30) vs. 3.2%(1/31)
| Shingles: 0.0%(0/30) vs. 3.2%(1/31)
Hendrix SL et al., 2006 ^121^ | Estrogen vs. Placebo:
| Cerebrovascular death: 0.1%(7/5310) vs. 0.1%(4/5429)
| Glasgow outcome scale - death: 0.3%(17/5310) vs. 0.3%(15/5429)
| Glasgow outcome scale - good recovery: 0.9%(47/5310) vs. 0.7%(39/5429)
| Glasgow outcome scale - moderately disabled: 0.8%(44/5310) vs. 0.6%(30/5429)
| Glasgow outcome scale - not yet categorized: 0.0%(1/5310) vs. 0.0%(0/5429)
| Glasgow outcome scale - severely disabled: 0.8%(44/5310) vs. 0.5%(28/5429)
| Glasgow outcome scale - unable to categorize: 0.3%(15/5310) vs. 0.3%(14/5429)
| Glasgow outcome scale - vegetative survival: 0.0%(0/5310) vs. 0.0%(1/5429)
| Hemorrhagic stroke - intraparenchymal: 0.2%(10/5310) vs. 0.3%(18/5429)
| Hemorrhagic stroke - subarachnoid: 0.1%(6/5310) vs. 0.1%(8/5429)
| Ischemic stroke - cardioembolism: 0.5%(26/5310) vs. 0.2%(13/5429)
| Ischemic stroke - large-artery atherosclerosis: 0.2%(8/5310) vs. 0.1%(7/5429)
| Ischemic stroke - small-vessel occlusion: 0.6%(33/5310) vs. 0.4%(23/5429)
| Ischemic stroke of other determined origin: 9.0%(478/5310) vs. 12.0%(651/5429)
| Moderate or severe vasomotor symptoms (night sweats, hot flashes or both): 0.4%(22/5310) vs. 0.3%(18/5429)
| Other stroke: 0.0%(1/5310) vs. 0.0%(1/5429)
| Stroke - not yet categorized: 0.0%(1/5310) vs. 0.0%(0/5429)
Herd RJ et al., 1997 ^122^ | Etidronate vs. Placebo:
| Arthritis: 14.7%(11/75) vs. 13.0%(10/77)
| Back pain: 16.0%(12/75) vs. 18.2%(14/77)
| Diarrhea: 4.0%(3/75) vs. 6.5%(5/77)
| Dyspepsia and skin rash: 1.3%(1/75) vs. 0.0%(0/77)
| Dyspepsia: 4.0%(3/75) vs. 7.8%(6/77)
| Endometrial carcinoma: 1.3%(1/75) vs. 0.0%(0/77)
| Flu syndrome: 12.0%(9/75) vs. 11.7%(9/77)
| Headache and vertigo: 1.3%(1/75) vs. 0.0%(0/77)
| Infection: 24.0%(18/75) vs. 28.6%(22/77)
| Nausea: 4.0%(3/75) vs. 13.0%(10/77)
| Recurrent infection: 1.3%(1/75) vs. 0.0%(0/77)
| Serious AEs: 10.7%(8/75) vs. 9.1%(7/77)
| Worsening of arthritis: 1.3%(1/75) vs. 0.0%(0/77)
Herrera JA et al., 1999 ^123^ | Alendronate vs. Pamidronate:
| Dyspepsia: 4.8%(1/21) vs. 0.0%(0/19)
| Endoscopic severe lesion after 1 month: 23.8%(5/21) vs. 10.5%(2/19)
| Epigastralgia: 4.8%(1/21) vs. 0.0%(0/19)
Ho AY et al., 2005 ^124^ | Alendronate & calcium vs. Calcium:
| Abnormal liver function: 3.4%(1/29) vs. 0.0%(0/29)
| Constipation: 10.3%(3/29) vs. 10.3%(3/29)
| Dizziness: 3.4%(1/29) vs. 10.3%(3/29)
| Dry mouth: 0.0%(0/29) vs. 3.4%(1/29)
| Elevated liver transaminase enzymes secondary to viral hepatitis: 3.4%(1/29) vs. 0.0%(0/29)
| Flatulence: 10.3%(3/29) vs. 10.3%(3/29)
| Malaise: 3.4%(1/29) vs. 0.0%(0/29)
| Muscle cramps: 6.9%(2/29) vs. 3.4%(1/29)
| Musculoskeletal pain: 0.0%(0/29) vs. 3.4%(1/29)
Hooper MJ et al., 2005 ^125^ | Risedronate 2.5mg/d vs. Risedronate 5mg/d vs. Placebo:
| Abdominal pain: 7.0%(9/128) vs. 7.0%(9/129) vs. 4.8%(6/126)
| Duodenal ulcer: 0.8%(1/128) vs. 0.8%(1/129) vs. 0.0%(0/126)
| Dyspepsia: 10.2%(13/128) vs. 6.2%(8/129) vs. 9.5%(12/126)
| Esophageal ulcer: 0.0%(0/128) vs. 0.8%(1/129) vs. 1.6%(2/126)
| Esophagitis: 0.8%(1/128) vs. 3.1%(4/129) vs. 3.2%(4/126)
| GI disorder: 2.3%(3/128) vs. 3.1%(4/129) vs. 1.6%(2/126)
| Gastritis: 2.3%(3/128) vs. 1.6%(2/129) vs. 2.4%(3/126)
| Stomach ulcer: 0.8%(1/128) vs. 0.0%(0/129) vs. 0.8%(1/126)
Horwitz MJ et al., 2003 ^126^ | PTH vs. Placebo:
| Heart palpitations: 12.5%(1/8) vs. 0.0%(0/8)
| Shortness of breath and chest tightness: 0.0%(0/8) vs. 12.5%(1/8)
Hosking D et al., 1998 ^127^ | Alendronate 2.5mg vs. Alendronate 5mg vs. Estrogen-progestin vs. Placebo:
| Abdominal pain: 10.0%(50/499) vs. 9.0%(45/498) vs. 10.9%(12/110) vs. 12.0%(60/502)
| Acid regurgitation: 4.6%(23/499) vs. 4.8%(24/498) vs. 0.0%(0/110) vs. 4.4%(22/502)
| Any type of GI symptom: 30.5%(152/499) vs. 29.7%(148/498) vs. 28.2%(31/110) vs. 29.5%(148/502)
| Cardiovascular system AE: 10.0%(50/499) vs. 9.8%(49/498) vs. 13.6%(15/110) vs. 9.4%(47/502)
| Digestive system AE: 51.7%(258/499) vs. 53.2%(265/498) vs. 50.9%(56/110) vs. 52.4%(263/502)
| Dyspepsia: 9.2%(46/499) vs. 9.2%(46/498) vs. 5.5%(6/110) vs. 9.8%(49/502)
| Musculoskeletal system AE: 63.9%(319/499) vs. 61.8%(308/498) vs. 56.4%(62/110) vs. 59.6%(299/502)
| Nausea: 7.6%(38/499) vs. 7.6%(38/498) vs. 7.3%(8/110) vs. 7.4%(37/502)
| Nervous system/psychiatric AE: 29.9%(149/499) vs. 32.7%(163/498) vs. 32.7%(36/110) vs. 31.1%(156/502)
| Respiratory system AE: 74.9%(374/499) vs. 74.3%(370/498) vs. 70.9%(78/110) vs. 77.1%(387/502)
| Skin AE: 31.9%(159/499) vs. 32.5%(162/498) vs. 28.2%(31/110) vs. 33.1%(166/502)
| Urogenital system AE: 36.3%(181/499) vs. 32.9%(164/498) vs. 90.0%(99/110) vs. 33.5%(168/502)
| Vomiting: 3.4%(17/499) vs. 4.8%(24/498) vs. 2.7%(3/110) vs. 3.4%(17/502)
Hosking D et al., 2003 ^128^ | Alendronate vs. Risedronate vs. Placebo:
| Any adverse effects: 77.2%(169/219) vs. 76.1%(169/222) vs. 70.4%(76/108)
| Any upper gastrointestinal: 28.3%(62/219) vs. 27.5%(61/222) vs. 26.9%(29/108)
| Deglutition disorder: 0.0%(0/219) vs. 0.5%(1/222) vs. 0.0%(0/108)
| Dysphagia: 0.9%(2/219) vs. 0.0%(0/222) vs. 0.0%(0/108)
| Gastric ulcer: 0.0%(0/219) vs. 0.5%(1/222) vs. 0.0%(0/108)
| Esophagitis: 1.4%(3/219) vs. 0.9%(2/222) vs. 0.0%(0/108)
| One or more Esophageal AEs: 2.3%(5/219) vs. 1.8%(4/222) vs. 0.0%(0/108)
| One or more PUBs AEs: 0.0%(0/219) vs. 0.5%(1/222) vs. 0.0%(0/108)
| Reflux esophagitis: 0.0%(0/219) vs. 0.5%(1/222) vs. 0.0%(0/108)
| Serious upper gastrointestinal: 0.5%(1/219) vs. 0.0%(0/222) vs. 1.9%(2/108)
Howell SJ et al., 2001 ^129^ | Placebo vs. Testosterone:
| Serious AE: 0.0%(0/19) vs. 0.0%(0/16)
| Skin reaction: 5.3%(1/19) vs. 43.8%(7/16)
Hsia J et al., 2004 ^130^ | Conjugated estrogens 0.625mg/d & medroxyprogesterone acetate 2.5mg/d vs. Placebo:
| Peripheral artery disease (PAD)-abdominal aortic aneurysm (aaa): 0.1%(8/8506) vs. 0.1%(9/8102)
| PAD-carotid: 0.4%(31/8506) vs. 0.5%(39/8102)
| PAD-lower extremity: 0.3%(27/8506) vs. 0.3%(25/8102)
Hsia J et al., 2006 ^131^ | CEE vs. Placebo:
| CABG or PTCA: 4.8%(253/5310) vs. 5.1%(276/5429)
| Hospitalized CHF with wall motion abnormality: 1.1%(60/5310) vs. 1.3%(69/5429)
| Hospitalized CHF without wall motion abnormality: 2.4%(125/5310) vs. 2.1%(114/5429)
| Hospitalized angina (confirmed angina): 3.1%(163/5310) vs. 3.1%(171/5429)
| Hospitalized angina (unconfirmed angina): 1.9%(102/5310) vs. 1.7%(91/5429)
| Myocardial infarction: 2.4%(130/5310) vs. 2.6%(139/5429)
| Primary outcome: coronary death: 1.2%(62/5310) vs. 1.2%(63/5429)
| Primary outcome: nonfatal MI - other: 2.7%(142/5310) vs. 3.0%(161/5429)
| Primary outcome: nonfatal MI - silent MI: 0.1%(7/5310) vs. 0.1%(7/5429)
Hulley S et al., 1998 ^132^ | Estrogen+ Progesterone vs. Placebo:
| Breast cancer: 2.3%(32/1380) vs. 1.8%(25/1383)
| CHD Death: 5.1%(71/1380) vs. 4.2%(58/1383)
| Cancer death: 1.4%(19/1380) vs. 1.7%(24/1383)
| Coronary artery bypass graft surgery: 6.4%(88/1380) vs. 7.3%(101/1383)
| Deep vein thrombosis: 1.8%(25/1380) vs. 0.6%(8/1383)
| Endometrial cancer: 0.1%(2/1380) vs. 0.3%(4/1383)
| Gall bladder disease: 6.1%(84/1380) vs. 4.5%(62/1383)
| Hospitalization for congestive heart failure: 9.3%(128/1380) vs. 8.1%(112/1383)
| Hospitalization for unstable angina: 7.5%(103/1380) vs. 8.5%(117/1383)
| Non CHD death, non-cancer death: 2.7%(37/1380) vs. 2.6%(36/1383)
| Non fatal MI: 8.4%(116/1380) vs. 9.3%(129/1383)
| Other CHD event: 0.2%(3/1380) vs. 0.1%(1/1383)
| Other cancer: 4.6%(63/1380) vs. 4.2%(58/1383)
| Percutaneous coronary revascularization: 11.9%(164/1380) vs. 12.7%(175/1383)
| Peripheral arterial disease: 6.8%(94/1380) vs. 7.8%(108/1383)
| Pulmonary embolism: 0.8%(11/1380) vs. 0.3%(4/1383)
| Resuscitated cardiac arrest: 1.4%(19/1380) vs. 0.9%(13/1383)
| Stroke/transient ischemic attack (tia): 7.8%(108/1380) vs. 6.9%(96/1383)
| Unadjudicated death: 0.3%(4/1380) vs. 0.4%(5/1383)
Hulley S et al., 2002 ^133^ | Estrogen vs. Placebo:
| Any cancer: 4.2%(58/1380) vs. 3.2%(44/1383)
| Any death: 9.5%(131/1380) vs. 8.4%(116/1383)
| Biliary tract surgery: 2.9%(40/1380) vs. 1.7%(24/1383)
| Breast cancer: 1.1%(15/1380) vs. 1.0%(14/1383)
| Cardiovascular disease (CVD) death: 5.1%(71/1380) vs. 5.4%(74/1383)
| Cancer death: 2.2%(30/1380) vs. 1.4%(20/1383)
| Colon cancer: 0.7%(10/1380) vs. 0.7%(10/1383)
| Deep vein thrombosis: 0.9%(12/1380) vs. 0.7%(10/1383)
| Endometrial cancer: 0.0%(0/1380) vs. 0.2%(3/1383)
| Lung cancer: 0.9%(13/1380) vs. 0.6%(8/1383)
| Non-CVD, non-cancer death: 2.2%(30/1380) vs. 1.6%(22/1383)
| Other cancers: 1.7%(23/1380) vs. 0.9%(12/1383)
| Pulmonary embolism: 0.4%(6/1380) vs. 0.1%(2/1383)
| Total thromboembolic events: 1.1%(15/1380) vs. 0.8%(11/1383)
Huusko TM et al., 2002 ^134^ | Calcitonin vs. Placebo:
| Death - cause not stated: 5.0%(6/121) vs. 6.6%(8/122)
| Local irritation: 9.9%(12/121) vs. 5.7%(7/122)
Hwang JS et al., 2006 ^135^ | Calcitonin vs. Teriparatide:
| Any clinical AE: 100.0%(29/29) vs. 91.2%(31/34)
| Alkaline phosphatase increase: 3.4%(1/29) vs. 11.8%(4/34)
| Any drug-related AE: 31.0%(9/29) vs. 26.5%(9/34)
| Any serious AE: 3.4%(1/29) vs. 2.9%(1/34)
| Blood urea nitrogen increased: 3.4%(1/29) vs. 0.0%(0/34)
| Constipation: 3.4%(1/29) vs. 0.0%(0/34)
| Dizziness: 10.3%(3/29) vs. 5.9%(2/34)
| Dyspnea: 3.4%(1/29) vs. 0.0%(0/34)
| Gastrointestinal disorder: 3.4%(1/29) vs. 0.0%(0/34)
| Hypercalcemia: 0.0%(0/29) vs. 5.9%(2/34)
| Hyperuricemia: 3.4%(1/29) vs. 0.0%(0/34)
| Liver function abnormal: 3.4%(1/29) vs. 0.0%(0/34)
| Nausea: 3.4%(1/29) vs. 2.9%(1/34)
| Palpitations: 3.4%(1/29) vs. 0.0%(0/34)
| Rashes: 3.4%(1/29) vs. 0.0%(0/34)
| Vasodilation: 10.3%(3/29) vs. 0.0%(0/34)
| Vomiting: 10.3%(3/29) vs. 2.9%(1/34)
Ilter E et al., 2006 ^136^ | Risedronate 35mg/week vs. Risedronate 5mg/day vs. Placebo:
| Any AE: 53.7%(22/41) vs. 56.1%(23/41) vs. 53.7%(22/41)
| Gastrointestinal AE: 24.4%(10/41) vs. 29.3%(12/41) vs. 22.0%(9/41)
| Gastrointestinal, non serious: 17.1%(7/41) vs. 19.5%(8/41) vs. 14.6%(6/41)
| Non-serious AE: 43.9%(18/41) vs. 46.3%(19/41) vs. 43.9%(18/41)
| Upper gastrointestinal bleeding: 0.0%(0/41) vs. 2.4%(1/41) vs. 0.0%(0/41)
Ishida Y et al., 2004 ^137^ | Calcitonin vs. Estrogen vs. Etidronate vs. Vitamin D vs. Vitamin K vs. Control:
| Bleeding: 0.0%(0/66) vs. 3.0%(2/66) vs. 0.0%(0/66) vs. 0.0%(0/66) vs. 0.0%(0/66) vs. 0.0%(0/66)
| Breast tenderness: 0.0%(0/66) vs. 1.5%(1/66) vs. 0.0%(0/66) vs. 0.0%(0/66) vs. 0.0%(0/66) vs. 0.0%(0/66)
| GI symptoms: 0.0%(0/66) vs. 0.0%(0/66) vs. 1.5%(1/66) vs. 0.0%(0/66) vs. 0.0%(0/66) vs. 0.0%(0/66)
Iwamoto J et al., 2001 ^138^ | Calcium vs. Etidronate vs. Vitamin K:
| Gastrointestinal symptoms: 8.3%(2/24) vs. 20.0%(5/25) vs. 0.0%(0/23)
| Other adverse effect: 0.0%(0/24) vs. 0.0%(0/25) vs. 0.0%(0/23)
Iwamoto J et al., 2005 ^139^ | Alendronate 5 mg/d vs. Etidronate:
| Serious AE: 0.0%(0/25) vs. 0.0%(0/25)
| Thirst, itchy eruption, gastric pain, diarrhea: 4.0%(1/25) vs. 0.0%(0/25)
Jeffery JR et al., 2003 ^140^ | Alendronate vs. Vitamin D:
| Cardiac problems: 0.0%(0/60) vs. 1.8%(1/57)
| Death from sepsis: 1.7%(1/60) vs. 0.0%(0/57)
| Developed cancer: 0.0%(0/60) vs. 3.5%(2/57)
| Graft failure: 1.7%(1/60) vs. 0.0%(0/57)
| Not tolerate: 3.3%(2/60) vs. 3.5%(2/57)
| Relapse of colitis: 1.7%(1/60) vs. 0.0%(0/57)
Jeffrey J et al., 2003 ^141^ | Alendronate vs. Vitamin D:
| Death: 1.7%(1/60) vs. 0.0%(0/57)
Jodar E et al., 1997 ^142^ | Carbimazole vs. Carbimazole plus high-dose Calcitonin vs. Carbimazole plus low-dose Calcitonin:
| Aqueous rhinorrhea: 0.0%(0/15) vs. 7.1%(1/14) vs. 0.0%(0/14)
| Discomfort, nausea: 0.0%(0/15) vs. 21.4%(3/14) vs. 7.1%(1/14)
| Facial flushing: 0.0%(0/15) vs. 14.3%(2/14) vs. 0.0%(0/14)
| Headache: 0.0%(0/15) vs. 7.1%(1/14) vs. 0.0%(0/14)
Johnell O et al., 2002 ^143^ | Alendronate vs. Alendronate+Raloxifene vs. Raloxifene vs. Placebo:
| Abdominal pain: 10.8%(9/83) vs. 6.0%(5/84) vs. 7.3%(6/82) vs. 6.1%(5/82)
| Chest pain substernal: 7.2%(6/83) vs. 3.6%(3/84) vs. 4.9%(4/82) vs. 2.4%(2/82)
| Sweating: 2.4%(2/83) vs. 0.0%(0/84) vs. 1.2%(1/82) vs. 2.4%(2/82)
| Vasodilatation: 4.8%(4/83) vs. 4.8%(4/84) vs. 4.9%(4/82) vs. 4.9%(4/82)
Johnell O et al., 2004 ^144^ | No previous HT: Raloxifene vs. No previous HT: placebo vs. Previous HT: Placebo vs. Previous HT: Raloxifene:
| Breast cancer: 0.6%(23/3614) vs. 1.5%(27/1833) vs. 2.3%(17/738) vs. 0.7%(11/1497)
| Cardiovascular events: 3.7%(133/3614) vs. 4.2%(76/1833) vs. 2.7%(20/738) vs. 2.9%(43/1497)
| Cardiovascular events in high risk subgroup: 8.5%(309/3614) vs. 13.1%(240/1833) vs. 12.7%(93/738) vs. 5.9%(88/1497)
| Cerebrovascular events: 1.6%(59/3614) vs. 1.8%(32/1833) vs. 1.2%(9/738) vs. 1.1%(17/1497)
| Coronary events: 2.1%(75/3614) vs. 2.4%(44/1833) vs. 1.5%(11/738) vs. 1.7%(26/1497)
| Invasive breast cancer: 0.4%(14/3614) vs. 1.3%(23/1833) vs. 2.0%(15/738) vs. 0.5%(7/1497)
| Invasive estrogen-receptor positive breast cancer: 0.2%(6/3614) vs. 0.9%(16/1833) vs. 1.8%(13/738) vs. 0.3%(4/1497)
Johnston CC et al., 2000 ^145^ | Raloxifene 150 mg vs. Raloxifene 30 mg vs. Raloxifene 60 mg vs. Placebo:
| Abdominal pain: 9.1%(26/285) vs. 6.9%(20/288) vs. 5.6%(16/286) vs. 7.0%(20/286)
| Breast carcinoma: 0.4%(1/285) vs. 0.7%(2/288) vs. 0.0%(0/286) vs. 0.7%(2/286)
| Breast pain: 2.5%(7/285) vs. 2.4%(7/288) vs. 3.8%(11/286) vs. 3.8%(11/286)
| Deep thrombophlebitis: 0.0%(0/285) vs. 0.0%(0/288) vs. 0.3%(1/286) vs. 0.0%(0/286)
| Hot flashes: 23.5%(67/285) vs. 17.0%(49/288) vs. 25.2%(72/286) vs. 18.2%(52/286)
| Leg cramps: 4.9%(14/285) vs. 3.1%(9/288) vs. 4.9%(14/286) vs. 2.8%(8/286)
| Leukorrhea: 2.5%(7/285) vs. 2.4%(7/288) vs. 2.8%(8/286) vs. 1.0%(3/286)
| Nausea: 8.1%(23/285) vs. 5.9%(17/288) vs. 6.3%(18/286) vs. 8.0%(23/286)
| Peripheral edema: 2.5%(7/285) vs. 2.4%(7/288) vs. 4.5%(13/286) vs. 2.1%(6/286)
| Vaginal hemorrhage: 1.4%(4/285) vs. 0.3%(1/288) vs. 2.8%(8/286) vs. 3.5%(10/286)
| Vaginitis: 5.3%(15/285) vs. 5.9%(17/288) vs. 3.8%(11/286) vs. 4.2%(12/286)
Jolly EE et al., 2003 ^146^ | Raloxifene vs. Placebo:
| Endometrial thickness > 5mm: 18.9%(35/185) vs. 16.8%(24/143)
| Hot flashes: 25.4%(47/185) vs. 14.7%(21/143)
| Leg cramps: 6.5%(12/185) vs. 4.9%(7/143)
| Vaginal bleeding: 3.2%(6/185) vs. 2.8%(4/143)
| Venous thromboembolic events: 0.0%(0/185) vs. 0.0%(0/143)
Kananen K et al., 2005 ^147^ | Estrogen+Calcium+Vitamin D vs. Pamidronate:
| Death: 30.6%(15/49) vs. 26.0%(13/50)
| Secondary cancer: 0.0%(0/49) vs. 2.0%(1/50)
Kaufman JM et al., 2005 ^148^ | Teriparitide 20ug vs. Teriparitide 40ug vs. Placebo:
| Osteosarcoma: 0.0%(0/92) vs. 0.0%(0/84) vs. 0.0%(0/103)
Keegan TH et al., 2004 ^149^ | Alendronate diabetic vs. Alendronate non diabetic vs. Placebo diabetic vs. Placebo non diabetic:
| AE resulting in hospitalization: 10.8%(16/148) vs. 4.9%(151/3087) vs. 8.7%(13/149) vs. 4.8%(147/3074)
| Abdominal pain: 27.0%(40/148) vs. 13.1%(403/3087) vs. 14.8%(22/149) vs. 13.0%(400/3074)
| Acid regurgitation/reflux: 8.8%(13/148) vs. 8.5%(262/3087) vs. 6.7%(10/149) vs. 8.3%(255/3074)
| Any UGI event: 53.4%(79/148) vs. 43.2%(1334/3087) vs. 45.6%(68/149) vs. 43.2%(1327/3074)
| Esophageal ulcer: 0.7%(1/148) vs. 0.2%(6/3087) vs. 0.0%(0/149) vs. 0.2%(6/3074)
| Esophagitis: 2.7%(4/148) vs. 0.7%(22/3087) vs. 0.7%(1/149) vs. 0.4%(13/3074)
| Other esophageal: 2.0%(3/148) vs. 1.8%(57/3087) vs. 2.0%(3/149) vs. 1.6%(49/3074)
Kendler D et al., 2004 ^150^ | Alendronate once daily then once weekly vs. Alendronate once weekly then once daily:
| Body as a whole: 8.0%(16/205) vs. 10.0%(20/201)
| Digestive system: 10.0%(21/205) vs. 7.0%(14/201)
Kenny AM et al., 2001 ^151^ | Testosterone vs. Placebo:
| Elevated PSA: 17.6%(6/34) vs. 9.1%(3/33)
| Intercurrent illness: 11.8%(4/34) vs. 15.2%(5/33)
| Rash: 8.8%(3/34) vs. 3.0%(1/33)
| Rash with induration, score of 2 or greater: 77.0%(26/34) vs. 40.0%(13/33)
Kim SH et al., 2004 ^152^ | Pamidronate vs. Placebo:
| Hypocalcemia: 4.0%(1/25) vs. 0.0%(0/25)
Kishimoto H et al., 2006 ^153^ | Risedronate17.5 mg/w vs. Risedronate2.5/d:
| Abnormal Laboratory Parameters: 8.8%(22/249) vs. 15.0%(37/247)
| Drug Related - Other GI AE: 0.4%(1/249) vs. 2.4%(6/247)
| Drug Related Abdominal distention: 0.4%(1/249) vs. 1.6%(4/247)
| Drug Related Constipation: 2.4%(6/249) vs. 3.6%(9/247)
| Drug Related Dyspepsia: 0.4%(1/249) vs. 1.2%(3/247)
| Drug Related Gastritis: 0.8%(2/249) vs. 1.2%(3/247)
| Drug Related Stomach discomfort: 6.0%(15/249) vs. 5.3%(13/247)
| Drug Related Upper Abdominal pain: 1.6%(4/249) vs. 2.0%(5/247)
| Other AE: 51.4%(128/249) vs. 40.1%(99/247)
| Other Drug Related AEs: 12.9%(32/249) vs. 14.6%(36/247)
Kotaniemi A et al., 1996 ^154^ | Calcitonin+ Calcium vs. Control+ Calcium:
| Adverse event: 25.0%(8/32) vs. 16.1%(5/31)
| Dyspepsia: 0.0%(0/32) vs. 6.5%(2/31)
| Facial flush: 9.4%(3/32) vs. 0.0%(0/31)
| Gingival pain: 0.0%(0/32) vs. 3.2%(1/31)
| Hip arthroplasty: 0.0%(0/32) vs. 3.2%(1/31)
| Increased joint pain & morning stiffness: 0.0%(0/32) vs. 3.2%(1/31)
| Loose stools: 0.0%(0/32) vs. 3.2%(1/31)
| Metastatic cancer: 3.1%(1/32) vs. 0.0%(0/31)
Kristensen B et al., 1994 ^155^ | Control vs. Tamoxifen:
| Hot flushes: 12.0%(3/25) vs. 20.0%(5/25)
| Recurrence of breast cancer AFTER trial stopped: 8.0%(2/25) vs. 4.0%(1/25)
Kung AW et al., 2000 ^156^ | Alendronate vs. Placebo:
| Acid regurgitation: 0.0%(0/35) vs. 2.9%(1/35)
| Acute antral gastric ulcer: 2.9%(1/35) vs. 0.0%(0/35)
| Antral gastric ulcer - upper intestinal bleeding: 2.9%(1/35) vs. 0.0%(0/35)
| Chest pain: 0.0%(0/35) vs. 2.9%(1/35)
| Constipation: 8.6%(3/35) vs. 5.7%(2/35)
| Dizziness: 2.9%(1/35) vs. 8.6%(3/35)
| Dry mouth: 0.0%(0/35) vs. 2.9%(1/35)
| Esophageal ulcer: 0.0%(0/35) vs. 0.0%(0/35)
| Flatulence: 8.6%(3/35) vs. 8.6%(3/35)
| Gastric ulcer: 5.7%(2/35) vs. 0.0%(0/35)
| Gastritis: 0.0%(0/35) vs. 0.0%(0/35)
| Generalized muscle pain: 0.0%(0/35) vs. 2.9%(1/35)
| Malaise: 2.9%(1/35) vs. 0.0%(0/35)
| Mouth ulcer: 0.0%(0/35) vs. 2.9%(1/35)
| Muscle cramp: 8.6%(3/35) vs. 0.0%(0/35)
| Musculoskeletal pain: 0.0%(0/35) vs. 2.9%(1/35)
| Reflux esophagitis: 0.0%(0/35) vs. 0.0%(0/35)
Kung AW et al., 2003 ^157^ | Raloxifene vs. Placebo:
| Dizziness: 1.7%(8/483) vs. 2.9%(14/485)
| Dyspepsia: 2.9%(14/483) vs. 0.8%(4/485)
| Leg cramps: 4.3%(21/483) vs. 2.7%(13/485)
| Peripheral edema: 0.4%(2/483) vs. 0.4%(2/485)
| Serious treatment-emergent AE: 2.7%(13/483) vs. 2.5%(12/485)
| Sweating: 0.6%(3/483) vs. 0.6%(3/485)
| Vasodilatation: 5.6%(27/483) vs. 3.5%(17/485)
| Venous thromboembolic events: 0.0%(0/483) vs. 0.0%(0/485)
| Venous thromboembolism: 0.0%(0/483) vs. 0.0%(0/485)
Kung AW et al., 2006 ^158^ | Calcitonin vs. Teriparatide:
| Any AE: 73.7%(42/57) vs. 68.1%(32/47)
| Acute myocardial infarction: 0.0%(0/57) vs. 2.1%(1/47)
| Car accident: 1.8%(1/57) vs. 0.0%(0/47)
| Cerebral infarct: 0.0%(0/57) vs. 2.1%(1/47)
| Chest pain: 1.8%(1/57) vs. 0.0%(0/47)
| Contusion: 5.3%(3/57) vs. 0.0%(0/47)
| Cough: 7.0%(4/57) vs. 6.4%(3/47)
| Dizziness: 21.1%(12/57) vs. 10.6%(5/47)
| Fall and facial injury: 0.0%(0/57) vs. 2.1%(1/47)
| Flushing: 5.3%(3/57) vs. 0.0%(0/47)
| Headache: 8.8%(5/57) vs. 0.0%(0/47)
| Hot flush: 5.3%(3/57) vs. 0.0%(0/47)
| Injection site bruising: 0.0%(0/57) vs. 6.4%(3/47)
| Muscle cramp: 8.8%(5/57) vs. 2.1%(1/47)
| Musculoskeletal pain: 0.0%(0/57) vs. 2.1%(1/47)
| Nausea: 22.8%(13/57) vs. 12.8%(6/47)
| Pain in extremity: 5.3%(3/57) vs. 4.3%(2/47)
| Paresthesia: 5.3%(3/57) vs. 2.1%(1/47)
| Rash: 5.3%(3/57) vs. 2.1%(1/47)
| Signs of congestive heart failure and severe aortic stenosis with double vessel disease: 1.8%(1/57) vs. 0.0%(0/47)
| Transient ischemic attack: 1.8%(1/57) vs. 0.0%(0/47)
| UTI: 5.3%(3/57) vs. 2.1%(1/47)
| Upper respiratory tract infection: 1.8%(1/57) vs. 8.5%(4/47)
| Vomiting: 5.3%(3/57) vs. 4.3%(2/47)
Kurland ES et al., 2000 ^159^ | Control vs. PTH:
| Hypercalcemia: 0.0%(0/13) vs. 20.0%(2/10)
| Redness at the injection site: 7.7%(1/13) vs. 50.0%(5/10)
Kushida K et al., 2002 ^160^ | Alendronate vs. Vitamin D:
| Changes in lab test results that were considered clinically important: 14.5%(28/190) vs. 19.2%(34/175)
| Death: 0.0%(0/190) vs. 0.6%(1/175)
| Death (considered unrelated to the study treatment): 0.0%(0/190) vs. 0.6%(1/175)
| Gastric related symptoms(stomachache, heaviness, discomfort, fullness) and gastritis: 8.4%(16/190) vs. 5.7%(10/175)
| Gastrointestinal disorders: 18.4%(35/190) vs. 16.0%(28/175)
| People with =1 AE: 23.2%(44/190) vs. 21.7%(38/175)
Kushida K et al., 2004 ^161^ | Etidronate vs. Risedronate:
| Any AE: 93.1%(255/274) vs. 91.2%(249/273)
| Abdominal distension: 2.2%(6/274) vs. 0.7%(2/273)
| Abnormal laboratory parameters: 7.3%(20/274) vs. 10.6%(29/273)
| Any drug related AE: 32.8%(90/274) vs. 31.5%(86/273)
| Constipation: 2.2%(6/274) vs. 0.7%(2/273)
| Epigastric pain: 6.9%(19/274) vs. 6.2%(17/273)
| Gastrointestinal disorders**: 19.7%(54/274) vs. 17.6%(48/273)
| General disorders: 1.5%(4/274) vs. 2.6%(7/273)
| Musculoskeletal and connective tissue disorders: 2.9%(8/274) vs. 1.5%(4/273)
| Nausea: 1.8%(5/274) vs. 2.2%(6/273)
| Nervous system disorders: 3.3%(9/274) vs. 2.9%(8/273)
| Skin and subcutaneous disorders: 2.9%(8/274) vs. 2.2%(6/273)
Kushida K et al., 2004 ^162^ | Alendronate vs. Vitamin D:
| Abdominal pain: 0.0%(0/90) vs. 2.5%(2/80)
| Constipation: 3.3%(3/90) vs. 3.8%(3/80)
| Drug-related AEs - subjective symptoms/objective symptoms: 22.2%(20/90) vs. 16.3%(13/80)
| Drug-related AEs -laboratory abnormal findings: 12.2%(11/90) vs. 15.0%(12/80)
| Gastritis: 5.6%(5/90) vs. 3.8%(3/80)
| Incidence of gastrointestinal AEs: 14.4%(13/90) vs. 13.8%(11/80)
| Stomach discomfort: 2.2%(2/90) vs. 0.0%(0/80)
| Stomach heaviness: 2.2%(2/90) vs. 0.0%(0/80)
Lane NE et al., 1998 ^163^ | Estrogen vs. Estrogen+ PTH:
| Hypercalcemia: 0.0%(0/23) vs. 10.7%(3/28)
| Hypercalciuria: 4.3%(1/23) vs. 3.6%(1/28)
Lau EM et al., 2000 ^164^ | Alendronate vs. Placebo:
| Back pain: 1.9%(1/53) vs. 0.0%(0/47)
| Constipation: 1.9%(1/53) vs. 0.0%(0/47)
| Eye pain: 0.0%(0/53) vs. 2.1%(1/47)
| Leg pain: 1.9%(1/53) vs. 0.0%(0/47)
| Mild gastric discomfort: 3.8%(2/53) vs. 4.3%(2/47)
Lau EM et al., 2001 ^165^ | Alendronate vs. Placebo:
| Mild gastric discomfort: 10.0%(5/50) vs. 0.0%(0/50)
| Nausea/abdominal pain: 12.0%(6/50) vs. 8.0%(4/50)
| Vague musculoskeletal discomfort: 4.0%(2/50) vs. 0.0%(0/50)
Layton D et al., 2005 ^166^ | Raloxifene:
| Abnormal liver function tests: 0.1%(15/13987)
| Amaurosis fugax: 0.0%(5/13987)
| Amnesia: 0.2%(27/13987)
| Anaphylaxis: 0.0%(1/13987)
| Angioneurotic edema: 0.0%(2/13987)
| Anxiety: 0.9%(129/13987)
| Bradycardia: 0.0%(3/13987)
| Breast carcinoma: 0.2%(32/13987)
| Cardiovascular death: 0.2%(21/13987)
| Cataract: 0.0%(1/13987)
| Cerebrovascular attack, transient ischemic attack: 0.4%(60/13987)
| Cramp and limb pain: 3.4%(476/13987)
| Death - GI hemorrhage with a bleeding gastric ulcer: 0.0%(1/13987)
| Death - perforated duodenal ulcer: 0.0%(1/13987)
| Death - polycythemia rubra vera: 0.0%(1/13987)
| Death - thromboembolism (CVA, PE, myocardial infarction (MI)): 0.1%(14/13987)
| Death by neutropenia sepsis: 0.0%(1/13987)
| Death- GI hemorrhage: 0.0%(1/13987)
| Deaths (other): 0.7%(103/13987)
| Deep vein thrombosis: 0.1%(13/13987)
| Depression: 1.6%(222/13987)
| Diabetes mellitus: 0.3%(48/13987)
| Diarrhea: 1.1%(153/13987)
| Distension abdominal: 0.6%(84/13987)
| Dizziness: 1.0%(142/13987)
| Dyspepsia: 2.2%(302/13987)
| Edema: 1.9%(270/13987)
| Erythema multiforme: 0.0%(2/13987)
| Esophageal stricture: 0.0%(1/13987)
| Esophageal ulcer: 0.0%(1/13987)
| Flatulence: 0.2%(29/13987)
| Flushing: 6.5%(909/13987)
| Headache, migraine: 2.2%(302/13987)
| Hematuria: 0.1%(16/13987)
| Hemorrhage GI: 0.1%(10/13987)
| Hemorrhage rectal: 0.2%(27/13987)
| Hemorrhage vaginal: 0.6%(79/13987)
| Hyperlipidemia: 0.2%(21/13987)
| Hypertension: 1.1%(156/13987)
| Insomnia: 0.6%(83/13987)
| Intolerance: 1.6%(228/13987)
| Ischemic heart disease: 0.5%(67/13987)
| Jaundice: 0.0%(3/13987)
| Leukopenia: 0.0%(0/13987)
| Malaise, lassitude: 2.4%(335/13987)
| Malignancies: 0.8%(110/13987)
| Mastalgia: 0.8%(105/13987)
| Mood change: 0.1%(16/13987)
| Nausea, vomiting: 1.8%(253/13987)
| Neutropenia: 0.1%(7/13987)
| Paget's ductal carcinoma: 0.0%(1/13987)
| Pain abdomen: 1.6%(222/13987)
| Pain back: 1.8%(250/13987)
| Pain limb: 1.7%(241/13987)
| Peptic ulcer: 0.1%(8/13987)
| Pulmonary embolus: 0.1%(13/13987)
| Renal failure: 0.0%(3/13987)
| Respiratory tract infection higher: 3.0%(417/13987)
| Retinal vein thrombosis: 0.0%(2/13987)
| Stevens Johnson syndrome: 0.0%(1/13987)
| Sweating: 1.6%(229/13987)
| Thrombocytopenia: 0.0%(3/13987)
| Thrombophlebitis: 0.2%(31/13987)
| Unspecified side effects: 0.6%(90/13987)
| Urogenital bleeding event: 0.9%(121/13987)
| Visual deterioration within 2 hours of the first dose in pt with history of left central retinal vein occlusion: 0.0%(1/13987)
Lees B et al., 1996 ^167^ | Pamidronate 150mg vs. Pamidronate 300mg vs. Placebo:
| Esophagitis: 0.0%(0/41) vs. 2.6%(1/38) vs. 0.0%(0/42)
| Flatulence: 0.0%(0/41) vs. 0.0%(0/38) vs. 2.4%(1/42)
| Leg-cramps: 0.0%(0/41) vs. 0.0%(0/38) vs. 2.4%(1/42)
| Nausea: 26.8%(11/41) vs. 31.6%(12/38) vs. 7.1%(3/42)
| Nausea/indigestion: 7.3%(3/41) vs. 26.3%(10/38) vs. 0.0%(0/42)
| Pyrexia: 2.4%(1/41) vs. 2.6%(1/38) vs. 0.0%(0/42)
| Skin rash: 2.4%(1/41) vs. 0.0%(0/38) vs. 0.0%(0/42)
| Trembling: 0.0%(0/41) vs. 2.6%(1/38) vs. 0.0%(0/42)
Lindsay R et al., 1997 ^168^ | Estrogen vs. Estrogen+ PTH:
| Back pain: 0.0%(0/17) vs. 5.9%(1/17)
| Breast cancer: 0.0%(0/17) vs. 5.9%(1/17)
| Otosclerosis: 0.0%(0/17) vs. 5.9%(1/17)
| Subcutaneous nodules at injection site: 0.0%(0/17) vs. 11.8%(2/17)
| Urinary tract infection & possible renal stone: 0.0%(0/17) vs. 5.9%(1/17)
Lindsay R et al., 1999 ^169^ | Alendronate, Estrogen vs. Estrogen+ Placebo:
| Back pain: 10.0%(21/214) vs. 3.0%(6/214)
| GI adverse events: 10.7%(23/214) vs. 10.7%(23/214)
| Serious AE: 6.0%(13/214) vs. 8.0%(17/214)
Lindsay R et al., 2002 ^170^ | CEE 0.3mg vs. CEE 0.3mg/MPA 1.5mg vs. CEE 0.45/MPA 1.5mg vs. CEE 0.45mg vs. CEE 0.45mg/MPA 2.5mg vs. CEE 0.625 vs. CEE 0.625/MPA 2.5mg vs. Placebo:
| AE: 6.3%(6/96) vs. 1.9%(2/107) vs. 7.8%(8/103) vs. 10.6%(11/104) vs. 4.6%(5/108) vs. 21.4%(22/103) vs. 6.1%(6/98) vs. 2.9%(3/103)
Liu JL et al., 2004 ^171^ | Raloxifene vs. Placebo:
| Allergic dermatitis: 2.0%(2/102) vs. 0.0%(0/102)
| Arrhythmia: 2.0%(2/102) vs. 1.0%(1/102)
| Cerebrovascular disorder: 2.0%(2/102) vs. 0.0%(0/102)
| Diarrhea: 1.0%(1/102) vs. 5.9%(6/102)
| Enteritis: 1.0%(1/102) vs. 2.9%(3/102)
| Exostosis: 0.0%(0/102) vs. 2.0%(2/102)
| Herpes zoster: 0.0%(0/102) vs. 2.9%(3/102)
| Hot flushes: 2.9%(3/102) vs. 1.0%(1/102)
| Hypertension: 2.0%(2/102) vs. 3.9%(4/102)
| Muscle cramps: 8.8%(9/102) vs. 3.9%(4/102)
| Nasopharyngitis: 16.7%(17/102) vs. 19.6%(20/102)
| Non-specific urethritis: 2.9%(3/102) vs. 0.0%(0/102)
| Serious adverse events*: 2.0%(2/102) vs. 4.9%(5/102)
| UTI: 2.0%(2/102) vs. 2.0%(2/102)
| Uri: 3.9%(4/102) vs. 1.0%(1/102)
Love RR et al., 1992 ^172^ | Tamoxifen vs. Placebo:
| Breast cancer recurrence resulting in dropout: 2.9%(2/70) vs. 7.1%(5/70)
| Depression and hot flashes: 2.9%(2/70) vs. 0.0%(0/70)
| Dropout because of AEs: 7.1%(5/70) vs. 5.7%(4/70)
Luckey M et al., 2004 ^173^ | Alendronate vs. Raloxifene:
| Any AE: 73.5%(164/223) vs. 74.2%(173/233)
| Abdominal pain: 3.2%(7/223) vs. 1.7%(4/233)
| Any UGI AE: 17.0%(38/223) vs. 15.5%(36/233)
| Any drug related AE: 25.6%(57/223) vs. 26.6%(62/233)
| Any drug related UGI AE: 10.8%(24/223) vs. 10.3%(24/233)
| Any drug related vasomotor AE: 4.0%(9/223) vs. 6.9%(16/233)
| Any serious AE: 4.9%(11/223) vs. 6.9%(16/233)
| Any vasomotor AE: 4.5%(10/223) vs. 7.3%(17/233)
| Deep venous thrombosis: 0.0%(0/223) vs. 0.4%(1/233)
| Dyspepsia: 3.2%(7/223) vs. 2.6%(6/233)
| Heartburn: 2.7%(6/223) vs. 1.7%(4/233)
| Nausea: 5.9%(13/223) vs. 5.2%(12/233)
| Serious upper GI - abdominal pain: 0.0%(0/223) vs. 0.4%(1/233)
| Serious upper GI - gastroenteritis: 0.0%(0/223) vs. 0.4%(1/233)
| Serious upper GI - microperforation of the distal duodenum: 0.4%(1/223) vs. 0.0%(0/233)
Luckey MM et al., 2003 ^174^ | Alendronate 35mg once weekly vs. Alendronate 5mg daily:
| Abdominal distention: 2.8%(10/362) vs. 3.3%(12/361)
| Abdominal pain: 7.2%(26/362) vs. 5.8%(21/361)
| Acid regurgitation: 6.9%(25/362) vs. 6.1%(22/361)
| Dyspepsia: 4.4%(16/362) vs. 4.4%(16/361)
| Esophagitis: 0.0%(0/362) vs. 0.0%(0/361)
| Gastric ulcer: 0.3%(1/362) vs. 0.0%(0/361)
| Nausea: 3.9%(14/362) vs. 6.1%(22/361)
| Patients with one or more upper GI adverse experiences: 25.1%(91/362) vs. 24.1%(87/361)
| Vomiting: 2.5%(9/362) vs. 5.0%(18/361)
Luengo M et al., 1994 ^175^ | Calcitonin vs. Control:
| Facial redness: 9.1%(2/22) vs. 0.0%(0/22)
| Generalized pruritis: 4.5%(1/22) vs. 0.0%(0/22)
| Nausea alone: 9.1%(2/22) vs. 0.0%(0/22)
| Rhinorrhea: 9.1%(2/22) vs. 0.0%(0/22)
| Rhinorrhea and nausea: 4.5%(1/22) vs. 0.0%(0/22)
Lufkin EG et al., 1992 ^176^ | Estrogen+ Progesterone vs. Placebo:
| Breast cancer: 2.8%(1/36) vs. 2.6%(1/39)
| Breast tenderness: 55.6%(20/36) vs. 5.1%(2/39)
| Endometrial hyperplasia: 8.3%(3/36) vs. 0.0%(0/39)
| Skin irritation: 11.1%(4/36) vs. 10.3%(4/39)
Lufkin EG et al., 1994 ^177^ | Pamidronate vs. Placebo:
| Erosive esophagitis causing severe epigastric pain, dysphagia, vomiting: 12.1%(4/33) vs. 0.0%(0/16)
| Erosive esophagitis resulting in severe epigastric pain, dysphagia, vomiting: 15.2%(5/33) vs. 0.0%(0/16)
| Hiatal hernia: 6.1%(2/33) vs. 0.0%(0/16)
| Weight loss: 3.0%(1/33) vs. 0.0%(0/16)
Lyritis GP et al., 1997 ^178^ | Calcitonin vs. Placebo:
| Mild symptoms, mostly headache: 12.0%(6/50) vs. 0.0%(0/50)
Lyritis GP et al., 1999 ^179^ | Calcitonin vs. Placebo:
| Enteric disturbances: 5.0%(1/20) vs. 0.0%(0/20)
| Mild dizziness: 36.8%(7/20) vs. 6.3%(1/20)
| Mild enteric disturbance: 57.9%(12/20) vs. 43.8%(9/20)
Mackay FJ et al., 1998 ^180^ | Alendronate:
| Asthma, wheezing: 1.2%(19/1523)
| Back pain: 2.8%(43/1523)
| Constipation: 1.1%(17/1523)
| Cough: 1.4%(22/1523)
| Diarrhea: 2.6%(39/1523)
| Dizziness: 1.0%(15/1523)
| Dyspepsia: 6.0%(91/1523)
| Headache, migraine: 1.3%(20/1523)
| Joint pain: 2.2%(33/1523)
| Malaise, lassitude: 2.8%(43/1523)
| Nausea, vomiting: 4.4%(67/1523)
| Pain abdomen: 4.0%(61/1523)
| Respiratory tract infection: 7.7%(117/1523)
| UTI: 2.0%(31/1523)
Manson JE et al., 2003 ^181^ | Estrogen with progestin vs. Placebo:
| Acute coronary syndrome: 3.8%(322/8506) vs. 3.7%(299/8102)
| CABG or PTCA: 2.5%(214/8506) vs. 2.5%(205/8102)
| CHD - death: 0.5%(39/8506) vs. 0.4%(34/8102)
| CHD - nonfatal MI - other: 1.7%(147/8506) vs. 1.3%(109/8102)
| CHD - nonfatal MI - silent MI: 0.0%(4/8506) vs. 0.1%(5/8102)
| Congestive heart failure: 1.3%(113/8506) vs. 1.3%(109/8102)
| Hospitalization for angina (angina confirmed): 1.2%(106/8506) vs. 1.6%(126/8102)
| Hospitalization for angina (unconfirmed): 0.8%(66/8506) vs. 0.9%(69/8102)
| Hot flashes, night sweats, or both: 0.2%(21/8506) vs. 0.2%(17/8102)
| Other CHD AE: 0.4%(37/8506) vs. 0.4%(33/8102)
Masud T et al., 1998 ^182^ | Etidronate vs. Etidronate+ Vitamin D:
| Mild asymptomatic hypercalcemia: 0.0%(0/28) vs. 3.3%(1/30)
| Mild rash: 0.0%(0/28) vs. 3.3%(1/30)
| Minor gastrointestinal side effects: 10.7%(3/28) vs. 3.3%(1/30)
McClung M et al., 1998 ^183^ | Alendronate 10mg/d vs. Alendronate 20/0 mg/d vs. Alendronate 5mg/d vs. Alendronate 1 mg/d vs. Placebo:
| >=1 clinically significant UGI AE: 29.5%(26/88) vs. 31.5%(28/89) vs. 26.1%(23/88) vs. 26.1%(24/92) vs. 28.9%(26/90)
| At least one AE: 97.7%(86/88) vs. 94.4%(84/89) vs. 92.0%(81/88) vs. 92.4%(85/92) vs. 91.1%(82/90)
| Flatulence: 5.7%(5/88) vs. 5.6%(5/89) vs. 1.1%(1/88) vs. 1.1%(1/92) vs. 1.1%(1/90)
| Odynophagia: 3.4%(3/88) vs. 3.4%(3/89) vs. 0.0%(0/88) vs. 0.0%(0/92) vs. 0.0%(0/90)
| One or more AE: 97.7%(86/88) vs. 94.4%(84/89) vs. 92.0%(81/88) vs. 92.4%(85/92) vs. 91.1%(82/90)
| One or more clinically sign. Upper GI AE: 29.5%(26/88) vs. 31.5%(28/89) vs. 26.1%(23/88) vs. 26.1%(24/92) vs. 28.9%(26/90)
| Serious AE: 14.8%(13/88) vs. 14.8%(13/88) vs. 9.0%(8/89) vs. 9.0%(8/89) vs. 11.4%(10/88) vs. 11.4%(10/88) vs. 5.4%(5/92) vs. 5.4%(5/92) vs. 10.0%(9/90) vs. 10.0%(9/90)
McClung MR et al., 2001 ^184^ | Risedronate 2.5mg vs. Risedronate 5mg vs. Placebo:
| Any AE: 89.3%(2762/3093) vs. 89.8%(2786/3104) vs. 89.5%(2805/3134)
| Abdominal pain: 8.2%(255/3093) vs. 8.1%(250/3104) vs. 9.2%(288/3134)
| Any AE of upper GI tract: 22.3%(690/3093) vs. 21.2%(657/3104) vs. 21.8%(684/3134)
| Dyspepsia: 8.4%(259/3093) vs. 8.2%(255/3104) vs. 8.1%(254/3134)
| Esophageal ulcer: 0.3%(9/3093) vs. 0.3%(9/3104) vs. 0.4%(14/3134)
| Esophagitis: 1.5%(47/3093) vs. 1.7%(54/3104) vs. 1.9%(59/3134)
| Mod to severe: 8.4%(259/3093) vs. 9.0%(279/3104) vs. 8.2%(258/3134)
| Serious AE: 30.6%(946/3093) vs. 30.4%(943/3104) vs. 31.0%(973/3134)
McClung MR et al., 2004 ^185^ | Ibandronate 0.5mg vs. Ibandronate 1mg vs. Ibandronate 2.5mg vs. Placebo:
| Any AE: 92.0%(149/162) vs. 95.0%(158/166) vs. 98.0%(160/163) vs. 93.0%(151/162)
| Any drug related AE: 12.0%(19/162) vs. 13.0%(22/166) vs. 9.0%(15/163) vs. 12.0%(19/162)
| Any drug related serious AE: 0.0%(0/162) vs. 0.0%(0/166) vs. 0.0%(0/163) vs. 0.0%(0/162)
| Any serious AE: 6.0%(10/162) vs. 13.0%(22/166) vs. 5.0%(8/163) vs. 8.0%(13/162)
| Dyspepsia: 16.0%(26/162) vs. 14.0%(23/166) vs. 15.0%(24/163) vs. 14.0%(23/162)
| Dysphagia: 2.0%(3/162) vs. 1.0%(2/166) vs. 1.0%(2/163) vs. 0.0%(0/162)
| Eructation: 1.0%(2/162) vs. 1.0%(2/166) vs. 1.0%(2/163) vs. 1.0%(2/162)
| Esophagitis: 1.0%(2/162) vs. 0.0%(0/166) vs. 1.0%(2/163) vs. 1.0%(2/162)
| GI carcinoma: 0.0%(0/162) vs. 0.0%(0/166) vs. 1.0%(2/163) vs. 0.0%(0/162)
| GI disorder: 1.0%(2/162) vs. 2.0%(3/166) vs. 0.0%(0/163) vs. 3.0%(5/162)
| GI hemorrhage: 0.0%(0/162) vs. 0.0%(0/166) vs. 0.0%(0/163) vs. 1.0%(2/162)
| GI pain: 2.0%(3/162) vs. 0.0%(0/166) vs. 4.0%(7/163) vs. 4.0%(6/162)
| Gastritis: 0.0%(0/162) vs. 1.0%(2/166) vs. 2.0%(3/163) vs. 1.0%(2/162)
| Gastroenteritis: 9.0%(15/162) vs. 4.0%(7/166) vs. 5.0%(8/163) vs. 6.0%(10/162)
| Hemorrhagic gastritis: 1.0%(2/162) vs. 0.0%(0/166) vs. 0.0%(0/163) vs. 0.0%(0/162)
| Nausea: 6.0%(10/162) vs. 1.0%(2/166) vs. 4.0%(7/163) vs. 3.0%(5/162)
| Vomiting: 2.0%(3/162) vs. 0.0%(0/166) vs. 1.0%(2/163) vs. 0.0%(0/162)
McClung MR et al., 2004 ^186^ | Alendronate 2.5mg vs. Alendronate 5mg vs. Placebo:
| Acid regurgitation: 9.7%(16/165) vs. 5.4%(9/168) vs. 6.7%(17/252)
| Digestive system disorders: 69.1%(114/165) vs. 71.4%(120/168) vs. 64.7%(163/252)
| Dyspepsia: 15.8%(26/165) vs. 18.5%(31/168) vs. 13.9%(35/252)
| Laboratory: one or more AE: 26.7%(44/165) vs. 20.8%(35/168) vs. 27.8%(70/252)
| Nausea: 7.3%(12/165) vs. 10.7%(18/168) vs. 13.1%(33/252)
| One or more AE: 95.8%(158/165) vs. 96.4%(162/168) vs. 94.0%(237/252)
| Serious AE: 18.8%(31/165) vs. 15.5%(26/168) vs. 16.3%(41/252)
| Vomiting: 7.3%(12/165) vs. 7.7%(13/168) vs. 7.1%(18/252)
McClung MR et al., 2005 ^187^ | Alendronate vs. PTH:
| Hypercalcemia: 0.0%(0/101) vs. 2.9%(3/102)
| Moderate to severe back pain: 33.0%(33/101) vs. 15.0%(15/102)
| New or worsening back pain: 39.0%(39/101) vs. 26.0%(27/102)
| Severe back pain: 12.0%(12/101) vs. 4.0%(4/102)
McClung MR et al., 2006 ^188^ | Alendronate vs. Denosumab vs. Placebo:
| Any AE: 91.3%(42/46) vs. 87.3%(274/314) vs. 89.1%(41/46)
| Abnormal clinical laboratory investigation: 0.0%(0/46) vs. 0.3%(1/314) vs. 0.0%(0/46)
| Arthralgia: 6.5%(3/46) vs. 15.0%(47/314) vs. 23.9%(11/46)
| Back pain: 8.7%(4/46) vs. 11.5%(36/314) vs. 8.7%(4/46)
| Cardiac disorder: 0.0%(0/46) vs. 0.6%(2/314) vs. 4.3%(2/46)
| Contusion: 2.2%(1/46) vs. 5.1%(16/314) vs. 4.3%(2/46)
| Death: 0.0%(0/46) vs. 0.0%(0/314) vs. 0.0%(0/46)
| Diarrhea: 4.3%(2/46) vs. 6.7%(21/314) vs. 6.5%(3/46)
| Dyspepsia: 26.1%(12/46) vs. 8.6%(27/314) vs. 6.5%(3/46)
| Gastroesophageal reflux: 8.7%(4/46) vs. 7.0%(22/314) vs. 2.2%(1/46)
| General disorder: 0.0%(0/46) vs. 0.6%(2/314) vs. 0.0%(0/46)
| Headache: 10.9%(5/46) vs. 8.9%(28/314) vs. 13.0%(6/46)
| Hypertension: 8.7%(4/46) vs. 6.4%(20/314) vs. 0.0%(0/46)
| Infection: 0.0%(0/46) vs. 1.0%(3/314) vs. 0.0%(0/46)
| Influenza: 6.5%(3/46) vs. 8.0%(25/314) vs. 2.2%(1/46)
| Injury, poisoning or procedural complication: 0.0%(0/46) vs. 0.3%(1/314) vs. 2.2%(1/46)
| Metabolic and nutritional disorder: 2.2%(1/46) vs. 0.0%(0/314) vs. 0.0%(0/46)
| Musculoskeletal or connective-tissue disorder: 0.0%(0/46) vs. 0.6%(2/314) vs. 2.2%(1/46)
| Nasopharyngitis: 10.9%(5/46) vs. 14.6%(46/314) vs. 13.0%(6/46)
| Nausea: 17.4%(8/46) vs. 8.6%(27/314) vs. 4.3%(2/46)
| Neoplasm: 0.0%(0/46) vs. 1.9%(6/314) vs. 0.0%(0/46)
| Nervous system disorder: 0.0%(0/46) vs. 0.3%(1/314) vs. 0.0%(0/46)
| Pain in extremity: 10.9%(5/46) vs. 8.0%(25/314) vs. 8.7%(4/46)
| Rash: 4.3%(2/46) vs. 5.1%(16/314) vs. 0.0%(0/46)
| Serious AE: 2.2%(1/46) vs. 5.7%(18/314) vs. 4.3%(2/46)
| Sinusitis: 6.5%(3/46) vs. 6.1%(19/314) vs. 6.5%(3/46)
| Upper respiratory tract infection: 17.4%(8/46) vs. 19.4%(61/314) vs. 13.0%(6/46)
| Urinary tract infection: 6.5%(3/46) vs. 8.0%(25/314) vs. 0.0%(0/46)
| Vascular disorder: 0.0%(0/46) vs. 0.3%(1/314) vs. 0.0%(0/46)
Mellstrom DD et al., 2004 ^189^ | Risedronate vs. Risedronate+ Placebo:
| AE: 10.8%(9/83) vs. 9.9%(8/81)
| Abdominal pain: 3.6%(3/83) vs. 1.2%(1/81)
| Dyspepsia: 2.4%(2/83) vs. 2.5%(2/81)
| Dysphagia: 0.0%(0/83) vs. 1.2%(1/81)
| Esophagitis: 2.4%(2/83) vs. 0.0%(0/81)
| Moderate to severe upper GI tract AE: 3.6%(3/83) vs. 3.7%(3/81)
| Peptic ulcer: 2.4%(2/83) vs. 1.2%(1/81)
| Upper GI AE: 9.6%(8/83) vs. 8.6%(7/81)
Merza Z et al., 2006 ^190^ | Testosterone vs. Placebo:
| Hematocrit rise above reference range: 15.0%(3/20) vs. 5.3%(1/19)
Meunier PJ et al., 1997 ^191^ | Etidronate vs. Placebo:
| Abdominal pain: 14.8%(4/27) vs. 3.7%(1/27)
| Adverse effect: 96.3%(26/27) vs. 96.3%(26/27)
| Asthenia: 22.2%(6/27) vs. 29.6%(8/27)
| Constipation: 11.1%(3/27) vs. 0.0%(0/27)
| Diarrhea: 3.7%(1/27) vs. 14.8%(4/27)
| Dyspepsia: 11.1%(3/27) vs. 7.4%(2/27)
| Flatulence: 3.7%(1/27) vs. 11.1%(3/27)
| Flu syndrome: 18.5%(5/27) vs. 14.8%(4/27)
| Gastroenteritis: 3.7%(1/27) vs. 11.1%(3/27)
| Nausea: 14.8%(4/27) vs. 11.1%(3/27)
| Pain: 18.5%(5/27) vs. 18.5%(5/27)
| Serious AEs: 7.4%(2/27) vs. 22.2%(6/27)
| Severe gastrointestinal: 0.0%(0/27) vs. 0.0%(0/27)
Meunier PJ et al., 1999 ^192^ | Raloxifene 150mg vs. Raloxifene 60mg vs. Placebo:
| Deep venous thrombosis: 0.0%(0/42) vs. 0.0%(0/45) vs. 0.0%(0/42)
| Hot flushes: 14.3%(6/42) vs. 8.9%(4/45) vs. 9.5%(4/42)
| Retinal vein thrombosis: 0.0%(0/42) vs. 0.0%(0/45) vs. 2.4%(1/42)
Michalska D et al., 2006 ^193^ | Alendronate vs. Raloxifene vs. Placebo:
| Allergic skin reaction: 3.0%(1/33) vs. 0.0%(0/33) vs. 0.0%(0/33)
| Bone pain: 6.1%(2/33) vs. 0.0%(0/33) vs. 0.0%(0/33)
| Breast pain: 0.0%(0/33) vs. 3.0%(1/33) vs. 0.0%(0/33)
| Degenerative changes of the eye veins: 0.0%(0/33) vs. 3.0%(1/33) vs. 0.0%(0/33)
| Gastric pain: 3.0%(1/33) vs. 0.0%(0/33) vs. 0.0%(0/33)
| Headache: 0.0%(0/33) vs. 3.0%(1/33) vs. 0.0%(0/33)
| Hemorrhoids: 0.0%(0/33) vs. 3.0%(1/33) vs. 0.0%(0/33)
| Leg cramp: 0.0%(0/33) vs. 3.0%(1/33) vs. 3.0%(1/33)
| Lower back pain: 0.0%(0/33) vs. 6.1%(2/33) vs. 0.0%(0/33)
| Thrombophlebitis: 0.0%(0/33) vs. 3.0%(1/33) vs. 0.0%(0/33)
| Upper gastrointestinal symptoms: 6.1%(2/33) vs. 0.0%(0/33) vs. 3.0%(1/33)
Milgrom C et al., 2004 ^194^ | Risedronate vs. Placebo:
| Abdominal pain: 9.7%(16/165) vs. 10.1%(16/159)
| Diarrhea: 7.9%(13/165) vs. 7.5%(12/159)
| Headache: 17.6%(29/165) vs. 13.2%(21/159)
| Heart burn: 9.7%(16/165) vs. 17.0%(27/159)
| Nausea: 8.5%(14/165) vs. 5.7%(9/159)
| Polyarthralgia: 0.6%(1/165) vs. 0.0%(0/159)
| Total recruits with symptoms: 36.4%(60/165) vs. 42.8%(68/159)
| Vomiting: 2.4%(4/165) vs. 3.1%(5/159)
| Weakness: 19.4%(32/165) vs. 16.4%(26/159)
Miller PD et al., 1997 ^195^ | Control+ Calcium vs. Etidronate:
| Abdominal pain: 9.0%(9/100) vs. 15.1%(14/93)
| Death: 1.0%(1/100) vs. 0.0%(0/93)
| Diarrhea: 16.0%(16/100) vs. 12.9%(12/93)
| Nausea: 13.0%(13/100) vs. 12.9%(12/93)
Miller PD et al., 2000 ^196^ | Alendronate vs. Placebo:
| Abdominal pain: 14.8%(13/88) vs. 16.7%(14/84)
| Acid regurgitation: 25.0%(22/88) vs. 23.8%(20/84)
| Dyspepsia: 14.8%(13/88) vs. 21.4%(18/84)
| Esophagitis: 0.0%(0/88) vs. 0.0%(0/84)
| GI ulcer: 0.0%(0/88) vs. 0.0%(0/84)
| Gastritis: 0.0%(0/88) vs. 1.2%(1/84)
| Gastroesophageal reflux: 10.2%(9/88) vs. 11.9%(10/84)
| Nausea: 13.6%(12/88) vs. 15.5%(13/84)
| Serious AE considered not drug related: 2.3%(2/88) vs. 2.4%(2/84)
| Upper GI AE: 27.3%(24/88) vs. 28.6%(24/84)
| Vomiting: 3.4%(3/88) vs. 2.4%(2/84)
Miller PD et al., 2006 ^197^ | Teriparatide 20 mcg/d vs. Teriparatide 40 mcg/d vs. Placebo:
| Other AE: 80.2%(434/541) vs. 83.5%(461/552) vs. 84.7%(461/544)
| Renal related AE: 1.3%(7/541) vs. 1.6%(9/552) vs. 1.5%(8/544)
Miller et al., 1969 ^198^ | Estrogen vs. Placebo:
| Vaginal bleeding: 42.1%(8/19) vs. 10.5%(2/19)
Morabito N et al., 2002 ^199^ | Alendronate vs. Clodronate vs. Placebo:
| Abdominal pain: 11.1%(1/9) vs. 0.0%(0/8) vs. 0.0%(0/8)
| Pain at injection site: 0.0%(0/9) vs. 87.5%(7/8) vs. 0.0%(0/8)
Morabito N et al., 2003 ^200^ | Pamidronate vs. Pamidronate+ Fluoride:
| Fever after first infusion: 10.0%(2/20) vs. 15.0%(3/20)
| Mild gastric intolerance: 0.0%(0/20) vs. 5.0%(1/20)
Moran de Brito CM et al., 2005 ^201^ | Alendronate vs. Control:
| Constipation: 0.0%(0/10) vs. 11.1%(1/9)
Morii H et al., 2003 ^202^ | Raloxifene 120mg vs. Raloxifene 60mg vs. Placebo:
| Anaplastic thyroid carcinoma - death: 1.0%(1/100) vs. 0.0%(0/102) vs. 0.0%(0/100)
| Any AE related to drug: 40.0%(40/100) vs. 31.4%(32/102) vs. 33.0%(33/100)
| Cartilage injury: 0.0%(0/100) vs. 1.1%(1/102) vs. 0.0%(0/100)
| Clinically relevant change in ultrasound breast: 0.0%(0/100) vs. 0.0%(0/102) vs. 1.0%(1/100)
| Clinically relevant change physical exam of breast: 1.0%(1/100) vs. 0.0%(0/102) vs. 0.0%(0/100)
| Clinically relevant endometrial thickness change: 1.0%(1/100) vs. 2.0%(2/102) vs. 0.0%(0/100)
| Colitis ischemic: 0.0%(0/100) vs. 1.0%(1/102) vs. 1.0%(1/100)
| Convulsions NOS: 0.0%(0/100) vs. 0.0%(0/102) vs. 1.0%(1/100)
| Cystitis aggravated: 1.1%(1/100) vs. 0.0%(0/102) vs. 0.0%(0/100)
| Dissecting aortic aneurysm: 0.0%(0/100) vs. 1.0%(1/102) vs. 0.0%(0/100)
| Esophageal carcinoma NOS: 0.0%(0/100) vs. 0.0%(0/102) vs. 1.0%(1/100)
| Eye operation NOS: 0.0%(0/100) vs. 0.0%(0/102) vs. 1.0%(1/100)
| Gastric cancer recurrent: 0.0%(0/100) vs. 1.0%(1/102) vs. 0.0%(0/100)
| Gastrointestinal disorder NOS: 1.0%(1/100) vs. 0.0%(0/102) vs. 0.0%(0/100)
| Gastrointestinal infection NOS: 1.1%(1/100) vs. 0.0%(0/102) vs. 0.0%(0/100)
| Hypertension: 0.0%(0/100) vs. 0.0%(0/102) vs. 1.0%(1/100)
| Patients with any serious AE: 3.0%(3/100) vs. 4.9%(5/102) vs. 7.0%(7/100)
| Uterine prolapse: 0.0%(0/100) vs. 1.0%(1/102) vs. 0.0%(0/100)
Mortensen L et al., 1998 ^203^ | Risedronate 5 mg cyclical vs. Risedronate 5 mg daily vs. Placebo:
| Abdominal pain: 13.0%(5/38) vs. 8.0%(3/37) vs. 11.0%(4/36)
| Dyspepsia: 24.0%(9/38) vs. 16.0%(6/37) vs. 28.0%(10/36)
| Hip arthralgia: 2.6%(1/38) vs. 0.0%(0/37) vs. 0.0%(0/36)
Mosekilde L et al., 2000 ^204^ | Control vs. Estrogen:
| Arthritis and joint diseases: 4.2%(54/1293) vs. 4.4%(32/723)
| Breast cancer: 1.0%(13/1293) vs. 0.7%(5/723)
| Cardiovascular incidents: 0.5%(7/1293) vs. 0.6%(4/723)
| Cerebrovascular incidents: 0.5%(7/1293) vs. 0.3%(2/723)
| Cholecystectomies: 0.9%(12/1293) vs. 1.5%(11/723)
| Death: 1.3%(17/1293) vs. 1.0%(7/723)
| Diabetes: 0.4%(5/1293) vs. 0.7%(5/723)
| Hyperthyroidism: 0.9%(11/1293) vs. 0.8%(6/723)
| Hysterectomies: 1.5%(19/1293) vs. 1.9%(14/723)
| Lung disease: 2.2%(29/1293) vs. 1.9%(14/723)
| Other cancers: 0.7%(9/1293) vs. 0.8%(6/723)
| Venous thromboembolism: 0.0%(0/1293) vs. 0.0%(0/723)
Murphy MG et al., 2001 ^205^ | Alendronate vs. Alendronate+ HGH vs. HGH vs. Placebo:
| Abdominal distension: 0.0%(0/109) vs. 9.0%(10/111) vs. 0.0%(0/36) vs. 0.0%(0/36)
| Bloating/fluid retention: 0.9%(1/109) vs. 1.8%(2/111) vs. 0.0%(0/36) vs. 0.0%(0/36)
| Breast tenderness: 1.8%(2/109) vs. 0.0%(0/111) vs. 2.8%(1/36) vs. 0.0%(0/36)
| Carpal tunnel syndrome: 0.0%(0/109) vs. 0.9%(1/111) vs. 0.0%(0/36) vs. 2.8%(1/36)
| Esophageal ulcer: 0.9%(1/109) vs. 0.0%(0/111) vs. 0.0%(0/36) vs. 2.8%(1/36)
| Headache, night sweats, pain, hip/leg: 0.9%(1/109) vs. 0.9%(1/111) vs. 2.8%(1/36) vs. 0.0%(0/36)
| Heartburn: 0.9%(1/109) vs. 0.9%(1/111) vs. 0.0%(0/36) vs. 0.0%(0/36)
| Hyperglycemia: 0.0%(0/109) vs. 2.7%(3/111) vs. 0.0%(0/36) vs. 0.0%(0/36)
| Hyperprolactinemia: 0.0%(0/109) vs. 0.9%(1/111) vs. 2.8%(1/36) vs. 0.0%(0/36)
| Hypertension: 0.0%(0/109) vs. 1.8%(2/111) vs. 0.0%(0/36) vs. 0.0%(0/36)
| Indigestion / abdominal pain: 0.9%(1/109) vs. 0.0%(0/111) vs. 2.8%(1/36) vs. 2.8%(1/36)
| Rash: 0.0%(0/109) vs. 0.9%(1/111) vs. 0.0%(0/36) vs. 2.8%(1/36)
| Transaminase elevation: 0.0%(0/109) vs. 0.0%(0/111) vs. 5.6%(2/36) vs. 0.0%(0/36)
Nakayamada S et al., 2004 ^206^ | Etidronate+ Vitamin D vs. Vitamin D:
| Any adverse event: 0.0%(0/10) vs. 0.0%(0/11)
| Death - underlying disease: 0.0%(0/10) vs. 9.1%(1/11)
Neer RM et al., 2001 ^207^ | PTH 20 mcg vs. PTH 40mcg vs. Placebo:
| Cancer: 2.0%(11/541) vs. 2.0%(11/552) vs. 4.0%(22/544)
| Development of antibodies to PTH: 2.8%(15/541) vs. 8.0%(44/552) vs. 0.2%(1/544)
| Dizziness: 9.0%(49/541) vs. 0.0%(0/552) vs. 6.0%(33/544)
| Headache: 0.0%(0/541) vs. 13.0%(72/552) vs. 8.0%(44/544)
| Leg cramps: 3.0%(16/541) vs. 0.0%(0/552) vs. 1.0%(5/544)
| Mild hypercalcemia: 11.0%(60/541) vs. 28.0%(155/552) vs. 2.0%(11/544)
| Nausea: 0.0%(0/541) vs. 18.0%(99/552) vs. 8.0%(44/544)
| Persistent hypercalcemia: 2.8%(15/541) vs. 11.2%(62/552) vs. 0.6%(3/544)
Neven P et al., 2003 ^208^ | Estrogen vs. Raloxifene:
| Abdominal pain: 2.9%(15/513) vs. 2.0%(10/495)
| Bleeding/spotting rate of more than 3 days /28 days - core phase: 24.0%(123/513) vs. 0.2%(1/495)
| Bleeding/spotting rate of more than 3 days /28 days - extension phase: 10.2%(52/513) vs. 0.0%(0/495)
| Breast pain: 26.5%(136/513) vs. 1.8%(9/495)
| Breast pain - core phase: 26.5%(136/513) vs. 1.8%(9/495)
| Breast pain extension phase: 13.8%(71/513) vs. 0.8%(4/495)
| Cervix disorder: 2.7%(14/513) vs. 1.4%(7/495)
| Cervix neoplasm extension phase: 1.4%(7/513) vs. 0.0%(0/495)
| Death: 0.0%(0/513) vs. 0.2%(1/495)
| Emotional lability: 1.4%(7/513) vs. 0.0%(0/495)
| Endometrial thickness increase >2mm: 27.6%(142/513) vs. 10.2%(50/495)
| Enlarged uterine fibroids extension phase: 1.6%(8/513) vs. 0.2%(1/495)
| Flu syndrome: 4.3%(22/513) vs. 5.3%(26/495)
| Headache: 3.5%(18/513) vs. 2.0%(10/495)
| Leg cramps: 1.6%(8/513) vs. 2.6%(13/495)
| Edema: 0.4%(2/513) vs. 0.2%(1/495)
| Thrombophlebitis: 1.0%(5/513) vs. 0.0%(0/495)
| Vaginal hemorrhage: 3.7%(19/513) vs. 0.0%(0/495)
| Vaginal hemorrhage: 3.7%(19/513) vs. 0.0%(0/495)
| Vaginal hemorrhage extension phase: 1.4%(7/513) vs. 0.0%(0/495)
| Vaginitis: 2.1%(11/513) vs. 2.8%(14/495)
| Vasodilatation extension phase: 0.6%(3/513) vs. 2.6%(13/495)
| Vasodilation / menopause: 1.4%(7/513) vs. 6.7%(33/495)
| Weight gain: 2.5%(13/513) vs. 0.8%(4/495)
Neven P et al., 2004 ^209^ | Estrogen+ Progesterone vs. Raloxifene:
| Benign endometrial proliferation: 8.8%(45/513) vs. 1.2%(6/495)
| Cervical/endocervical abnormal: 0.8%(4/513) vs. 0.2%(1/495)
| Inflammatory: 0.6%(3/513) vs. 0.4%(2/495)
| Number of non-normal diagnoses: 41.9%(215/513) vs. 11.9%(59/495)
| Patients adjudicated as “other than normal”: 36.3%(186/513) vs. 10.7%(53/495)
| Polyp: 4.3%(22/513) vs. 2.0%(10/495)
| Preexisting polyp: 1.6%(8/513) vs. 0.6%(3/495)
Nickelsen T et al., 1999 ^210^ | Raloxifene 120 mg vs. Raloxifene 60 mg vs. Placebo:
| Death from pneumonia: 0.0%(0/47) vs. 2.1%(1/48) vs. 0.0%(0/48)
| Hot flashes: 12.8%(6/47) vs. 14.6%(7/48) vs. 10.4%(5/48)
Ninkovic M et al., 2002 ^211^ | Control vs. Pamidronate:
| Death: 20.4%(11/54) vs. 11.1%(5/45)
| Diarrhea: 0.0%(0/54) vs. 2.2%(1/45)
| Symptomatic fever: 0.0%(0/54) vs. 6.7%(3/45)
Notelovitz M et al., 2002 ^212^ | Estrogen 0.025mg vs. Estrogen 0.05mg vs. Estrogen 0.075mg vs. Placebo:
| Application site reaction: 52.8%(47/89) vs. 56.7%(51/90) vs. 55.1%(49/89) vs. 58.6%(51/87)
| Arthralgia: 5.6%(5/89) vs. 11.1%(10/90) vs. 12.4%(11/89) vs. 13.8%(12/87)
| Back pain: 5.6%(5/89) vs. 3.3%(3/90) vs. 7.9%(7/89) vs. 5.7%(5/87)
| Benign breast neoplasm: 3.4%(3/89) vs. 5.6%(5/90) vs. 1.1%(1/89) vs. 6.9%(6/87)
| Breast cancer: 1.1%(1/89) vs. 0.0%(0/90) vs. 1.1%(1/89) vs. 0.0%(0/87)
| Breast enlargement: 1.1%(1/89) vs. 2.2%(2/90) vs. 6.7%(6/89) vs. 3.4%(3/87)
| Breast pain: 14.6%(13/89) vs. 17.8%(16/90) vs. 34.8%(31/89) vs. 8.0%(7/87)
| Death: 2.2%(2/89) vs. 0.0%(0/90) vs. 0.0%(0/89) vs. 0.0%(0/87)
| Flu syndrome: 9.0%(8/89) vs. 13.3%(12/90) vs. 10.1%(9/89) vs. 10.3%(9/87)
| Headache: 11.2%(10/89) vs. 8.9%(8/90) vs. 5.6%(5/89) vs. 12.6%(11/87)
| Hypertension: 3.4%(3/89) vs. 3.3%(3/90) vs. 6.7%(6/89) vs. 3.4%(3/87)
| Myalgia: 3.4%(3/89) vs. 2.2%(2/90) vs. 5.6%(5/89) vs. 4.6%(4/87)
| Pain: 10.1%(9/89) vs. 5.6%(5/90) vs. 6.7%(6/89) vs. 12.6%(11/87)
| Pruritis: 2.2%(2/89) vs. 1.1%(1/90) vs. 6.7%(6/89) vs. 4.6%(4/87)
| Respiratory infection: 24.7%(22/89) vs. 24.4%(22/90) vs. 21.3%(19/89) vs. 26.4%(23/87)
| Sinusitis: 10.1%(9/89) vs. 12.2%(11/90) vs. 6.7%(6/89) vs. 18.4%(16/87)
Orwoll E et al., 2000 ^213^ | Alendronate vs. Placebo:
| Abdominal pain: 8.2%(12/146) vs. 4.2%(4/95)
| Acid regurgitation: 4.8%(7/146) vs. 5.3%(5/95)
| Any Upper GI event: 25.3%(37/146) vs. 22.1%(21/95)
| Cardiovascular system: 15.8%(23/146) vs. 16.8%(16/95)
| Digestive system: 34.9%(51/146) vs. 38.9%(37/95)
| Drug-related: 17.1%(25/146) vs. 13.7%(13/95)
| Dyspepsia: 6.2%(9/146) vs. 1.1%(1/95)
| Esophagitis: 0.7%(1/146) vs. 1.1%(1/95)
| High serum aspartate aminotransferase concentrations.: 0.7%(1/146) vs. 0.0%(0/95)
| Musculoskeletal system: 46.6%(68/146) vs. 52.6%(50/95)
| Nervous system: 25.3%(37/146) vs. 20.0%(19/95)
| Respiratory system: 45.2%(66/146) vs. 49.5%(47/95)
| Serious: 18.5%(27/146) vs. 23.2%(22/95)
| Skin: 22.6%(33/146) vs. 22.1%(21/95)
| Urogenital system: 17.1%(25/146) vs. 16.8%(16/95)
Orwoll ES et al., 2003 ^214^ | Teriparatide 20 mg vs. Teriparatide 40 mg vs. Placebo:
| Cancer: 2.0%(3/151) vs. 0.0%(0/139) vs. 2.0%(3/147)
| Death: 1.3%(2/151) vs. 0.0%(0/139) vs. 0.0%(0/147)
| Headache: 0.0%(0/151) vs. 0.7%(1/139) vs. 0.0%(0/147)
| Nausea: 5.3%(8/151) vs. 18.7%(26/139) vs. 3.4%(5/147)
| Osteosarcoma: 0.0%(0/151) vs. 0.0%(0/139) vs. 0.0%(0/147)
Palomba S et al., 2002 ^215^ | Alendronate 10mg vs. Alendronate 5mg vs. Placebo:
| Breast tenderness: 2.0%(1/50) vs. 0.0%(0/50) vs. 4.0%(2/50)
| Death due to MI: 0.0%(0/50) vs. 2.0%(1/50) vs. 0.0%(0/50)
| Gastralgia: 4.0%(2/50) vs. 2.0%(1/50) vs. 2.0%(1/50)
| Nausea: 2.0%(1/50) vs. 0.0%(0/50) vs. 2.0%(1/50)
| Upper GI: 4.0%(2/50) vs. 2.0%(1/50) vs. 2.0%(1/50)
| Vomiting: 0.0%(0/50) vs. 2.0%(1/50) vs. 2.0%(1/50)
Palomba S et al., 2005 ^216^ | Risedronate 3.5 mg/wk vs. Placebo:
| Back pain and arthralgia: 4.4%(2/45) vs. 0.0%(0/45)
| Gastrointestinal drug related AE (gastralgia and nausea): 4.4%(2/45) vs. 0.0%(0/45)
Peichl P et al., 1999 ^217^ | Calcitonin+ Calcium vs. Calcium+ Vitamin D:
| Transient local swelling of the nasal mucosa: 8.3%(2/24) vs. 0.0%(0/18)
Peichl P et al., 2005 ^218^ | Calcitonin+ Calcium+ Vitamin D vs. Calcium+ Vitamin D:
| Death: 5.4%(2/37) vs. 5.3%(2/38)
| Local swelling nasal mucosa: 5.4%(2/37) vs. 0.0%(0/38)
| Myocardial infarction: 2.7%(1/37) vs. 2.6%(1/38)
| Stroke: 5.4%(2/37) vs. 5.3%(2/38)
Pereda CA et al., 2002 ^219^ | Control vs. Estrogen:
| Osteoarthritis: 9.1%(1/11) vs. 0.0%(0/10)
| Severe migraine: 9.1%(1/11) vs. 0.0%(0/10)
Pitt P et al., 1997 ^220^ | Etidronate vs. Placebo:
| Accidental injury: 0.0%(0/26) vs. 17.4%(4/23)
| Back pain: 15.4%(4/26) vs. 0.0%(0/23)
| Death: 7.7%(2/26) vs. 4.3%(1/23)
| Moderate to severe upper GI AE: 0.0%(0/26) vs. 8.7%(2/23)
| Respiratory infections: 19.2%(5/26) vs. 8.7%(2/23)
Pitt P et al., 1998 ^221^ | Etidronate vs. Placebo:
| Accidental injury: 0.0%(0/26) vs. 17.4%(4/23)
| Back pain: 15.4%(4/26) vs. 0.0%(0/23)
| Death: 3.8%(1/26) vs. 4.3%(1/23)
| Moderate to severe upper GI adverse events: 0.0%(0/26) vs. 8.7%(2/23)
| One or more adverse event: 65.4%(17/26) vs. 82.6%(19/23)
| Respiratory infections: 19.2%(5/26) vs. 8.7%(2/23)
Pols HAP et al., 1999 ^222^ | Alendronate vs. Placebo:
| Abdominal pain: 10.0%(95/950) vs. 8.5%(81/958)
| Acid regurgitation: 2.3%(22/950) vs. 2.5%(24/958)
| Any upper gastrointestinal AE: 21.3%(202/950) vs. 19.3%(185/958)
| Duodenal ulcer: 0.0%(0/950) vs. 0.3%(3/958)
| Dyspepsia: 2.5%(24/950) vs. 2.3%(22/958)
| Dysphagia: 0.1%(1/950) vs. 0.2%(2/958)
| Esophagalgia: 0.2%(2/950) vs. 0.0%(0/958)
| Esophageal stricture: 0.1%(1/950) vs. 0.0%(0/958)
| Esophagitis: 0.4%(4/950) vs. 0.5%(5/958)
| Gastric ulcer: 0.4%(4/950) vs. 0.1%(1/958)
| Gastritis/gastroenteritis: 2.7%(26/950) vs. 2.1%(20/958)
| Nausea: 4.6%(44/950) vs. 3.9%(37/958)
| Odynophagia: 0.0%(0/950) vs. 0.1%(1/958)
| Reflux esophagitis: 0.4%(4/950) vs. 0.3%(3/958)
| Serious AEs: 6.5%(62/950) vs. 6.3%(60/958)
| Vomiting: 1.8%(17/950) vs. 2.5%(24/958)
Pouilles JM et al., 1997 ^223^ | Etidronate vs. Placebo:
| Abdominal pain: 13.0%(7/54) vs. 10.9%(6/55)
| At least one AE: 85.2%(46/54) vs. 83.6%(46/55)
| Digestive AE: 18.5%(10/54) vs. 34.5%(19/55)
| Moderate to severe UGI AE: 1.9%(1/54) vs. 3.6%(2/55)
| Serious AE: 13.0%(7/54) vs. 16.4%(9/55)
| Stomatitis: 1.9%(1/54) vs. 0.0%(0/55)
Ravn P et al., 1996 ^224^ | Ibandronate 0.25mg vs. Ibandronate 0.5mg vs. Ibandronate 1.0mg vs. Ibandronate 2.5mg vs. Ibandronate 5.0mg vs. Placebo:
| Breast cancer: 0.0%(0/30) vs. 3.3%(1/30) vs. 0.0%(0/30) vs. 0.0%(0/30) vs. 0.0%(0/30) vs. 0.0%(0/30)
| Cerebral hemorrhage leading to death: 0.0%(0/30) vs. 0.0%(0/30) vs. 0.0%(0/30) vs. 0.0%(0/30) vs. 0.0%(0/30) vs. 3.3%(1/30)
| Death from suspected MI: 0.0%(0/30) vs. 0.0%(0/30) vs. 0.0%(0/30) vs. 3.3%(1/30) vs. 0.0%(0/30) vs. 0.0%(0/30)
| Infection: 3.3%(1/30) vs. 0.0%(0/30) vs. 0.0%(0/30) vs. 3.3%(1/30) vs. 0.0%(0/30) vs. 3.3%(1/30)
| Non-serious GI AEs: 40.0%(12/30) vs. 56.7%(17/30) vs. 26.7%(8/30) vs. 16.7%(5/30) vs. 56.7%(17/30) vs. 36.7%(11/30)
| Stenosis of iliac artery: 0.0%(0/30) vs. 0.0%(0/30) vs. 0.0%(0/30) vs. 3.3%(1/30) vs. 0.0%(0/30) vs. 0.0%(0/30)
| Subanalysis of non-serious GI AEs (diarrhea only): 20.0%(6/30) vs. 16.7%(5/30) vs. 6.7%(2/30) vs. 6.7%(2/30) vs. 30.0%(9/30) vs. 6.7%(2/30)
| Tachycardia: 0.0%(0/30) vs. 0.0%(0/30) vs. 0.0%(0/30) vs. 0.0%(0/30) vs. 3.3%(1/30) vs. 0.0%(0/30)
Ravn P et al., 2000 ^225^ | Alendronate 20mg for 2yrs+ 3yr no therapy vs. Alendronate 5mg/d for 5yrs vs. Placebo 3yrs+ alendronate 5mg for 2yrs:
| Serious AE: 0.0%(0/52) vs. 0.0%(0/52) vs. 0.0%(0/56)
| Upper GI AE: 0.0%(0/52) vs. 0.0%(0/52) vs. 0.0%(0/56)
Recker R et al., 2004 ^226^ | Ibandronate 0.5 mg vs. Ibandronate 1 mg vs. Placebo:
| Musculoskeletal system: 52.3%(497/951) vs. 50.5%(485/961) vs. 51.4%(488/950)
| Skin and appendages: 19.4%(184/951) vs. 19.6%(188/961) vs. 23.4%(222/950)
| At least one adverse event: 94.3%(897/951) vs. 95.2%(915/961) vs. 94.1%(894/950)
| At least one serious adverse event: 25.2%(240/951) vs. 23.2%(223/961) vs. 26.7%(254/950)
| Cardiovascular system: 24.7%(235/951) vs. 22.9%(220/961) vs. 25.3%(240/950)
| Cataract: 0.1%(1/951) vs. 0.0%(0/961) vs. 0.0%(0/950)
| Cerebral infarction: 0.0%(0/951) vs. 0.1%(1/961) vs. 0.0%(0/950)
| Death: 0.8%(8/951) vs. 1.6%(15/961) vs. 1.4%(13/950)
| Digestive system: 40.5%(385/951) vs. 38.6%(371/961) vs. 39.9%(379/950)
| Dyspepsia: 0.0%(0/951) vs. 0.0%(0/961) vs. 0.1%(1/950)
| Eczema: 0.0%(0/951) vs. 0.0%(0/961) vs. 0.1%(1/950)
| Experienced at least one AE probably related to treatment: 15.0%(143/951) vs. 17.0%(163/961) vs. 10.0%(95/950)
| Hemic and lymphatic system: 8.2%(78/951) vs. 6.3%(61/961) vs. 6.5%(62/950)
| Hypertension: 0.0%(0/951) vs. 0.0%(0/961) vs. 0.1%(1/950)
| Injection site reactions: 2.3%(22/951) vs. 2.5%(24/961) vs. 0.1%(1/950)
| Metabolic and nutritional disorders: 17.3%(165/951) vs. 16.6%(160/961) vs. 15.5%(147/950)
| Myalgia: 5.1%(49/951) vs. 7.1%(68/961) vs. 3.4%(32/950)
| Nervous system: 25.2%(240/951) vs. 26.0%(250/961) vs. 26.8%(255/950)
| Respiratory system: 53.7%(511/951) vs. 52.9%(508/961) vs. 53.2%(505/950)
| Serious AE - Cardiovascular system: 6.6%(63/951) vs. 6.9%(66/961) vs. 7.2%(68/950)
| Serious AE - Digestive system: 4.3%(41/951) vs. 4.0%(38/961) vs. 4.4%(42/950)
| Serious AE - Endocrine system: 0.1%(1/951) vs. 0.2%(2/961) vs. 0.1%(1/950)
| Serious AE - Hemic and lymphatic system: 0.4%(4/951) vs. 0.6%(6/961) vs. 0.5%(5/950)
| Serious AE - Metabolic and nutritional disorders: 0.7%(7/951) vs. 0.3%(3/961) vs. 0.2%(2/950)
| Serious AE - Musculoskeletal system: 6.0%(57/951) vs. 4.7%(45/961) vs. 6.8%(65/950)
| Serious AE - Nervous system: 1.2%(11/951) vs. 2.0%(19/961) vs. 2.3%(22/950)
| Serious AE - Respiratory system: 2.8%(27/951) vs. 2.0%(19/961) vs. 2.0%(19/950)
| Serious AE - Skin and appendages: 2.0%(19/951) vs. 2.2%(21/961) vs. 2.7%(26/950)
| Serious AE - Special senses: 1.1%(10/951) vs. 0.7%(7/961) vs. 0.5%(5/950)
| Serious AE - Urogenital system: 1.9%(18/951) vs. 1.9%(18/961) vs. 2.1%(20/950)
| Serious AE - Whole body: 4.0%(38/951) vs. 3.5%(34/961) vs. 4.5%(43/950)
| Special senses: 15.8%(150/951) vs. 15.3%(147/961) vs. 17.1%(162/950)
| Urogenital system: 17.8%(169/951) vs. 19.3%(185/961) vs. 17.2%(163/950)
| Whole body: 56.1%(534/951) vs. 58.6%(563/961) vs. 56.1%(533/950)
Recker R et al., 2006 ^227^ | Alendronate vs. Alendronate, Vitamin D:
| 1 or more serious clinical AE: 4.2%(15/357) vs. 1.9%(7/360)
| Death: 0.0%(0/357) vs. 0.0%(0/360)
| Hypercalcemia: 0.0%(0/357) vs. 0.0%(0/360)
| Hypercalciuria: 3.9%(14/357) vs. 3.9%(14/360)
| Laboratory AE: 16.5%(59/357) vs. 4.4%(16/360)
Recker RR et al., 1999 ^228^ | Estrogen, Progesterone vs. Placebo:
| Atrophic endometrium: 3.1%(2/64) vs. 0.0%(0/64)
| Breast tenderness/ sensitivity: 76.6%(49/64) vs. 42.2%(27/64)
| Endometrial cancer: 0.0%(0/64) vs. 1.6%(1/64)
| Thromboembolic episode: 0.0%(0/64) vs. 0.0%(0/64)
| Vaginal spotting/change in vaginal discharge: 45.3%(29/64) vs. 0.0%(0/64)
Recker RR et al., 2006 ^229^ | Alendronate vs. Raloxifene:
| Cardiovascular AE (includes myocardial infarction, angina pectoris, unstable angina, carotid arte: 1.4%(10/716) vs. 0.8%(6/707)
| Diarrhea: 3.8%(27/716) vs. 1.6%(11/707)
| Hot flash, leg cramp, or venous thromboembolic AE (including embolism, flushing, hot flush, lower extremities: 7.3%(52/716) vs. 10.3%(73/707)
| Nausea: 5.3%(38/716) vs. 3.1%(22/707)
| Other type of AE: 32.3%(231/716) vs. 33.1%(234/707)
| Upper GI AE: 14.5%(104/716) vs. 10.9%(77/707)
Reginster J et al., 2000 ^230^ | Risedronate 2.5mg vs. Risedronate 5mg vs. Control:
| Any clinical event: 91.7%(374/408) vs. 91.9%(374/407) vs. 90.9%(370/407)
| AE: 13.0%(53/408) vs. 16.0%(65/407) vs. 20.4%(83/407)
| Abdominal pain: 8.8%(36/408) vs. 12.3%(50/407) vs. 7.9%(32/407)
| Any UGI symptoms: 23.0%(94/408) vs. 26.8%(109/407) vs. 25.6%(104/407)
| Duodenal ulcer: 0.5%(2/408) vs. 0.5%(2/407) vs. 0.2%(1/407)
| Duodenitis: 0.2%(1/408) vs. 0.5%(2/407) vs. 0.0%(0/407)
| Drug related AE: 26.7%(109/408) vs. 28.5%(116/407) vs. 31.7%(129/407)
| Dyspepsia: 9.3%(38/408) vs. 8.8%(36/407) vs. 10.8%(44/407)
| Esophageal ulcer: 1.0%(4/408) vs. 0.5%(2/407) vs. 0.7%(3/407)
| Esophagitis: 2.0%(8/408) vs. 2.5%(10/407) vs. 2.7%(11/407)
| Gastritis: 3.4%(14/408) vs. 2.2%(9/407) vs. 3.4%(14/407)
| Serious AE: 30.4%(124/408) vs. 37.1%(151/407) vs. 33.2%(135/407)
| Serious AE cancer: 2.9%(12/408) vs. 4.7%(19/407) vs. 4.2%(17/407)
| Serious AE cardiovascular: 7.4%(30/408) vs. 9.3%(38/407) vs. 9.3%(38/407)
| Stomach ulcer: 1.2%(5/408) vs. 1.5%(6/407) vs. 0.5%(2/407)
Reginster JY et al., 1987 ^231^ | Calcitonin+Calcium vs. Calcium:
| Gastrointestinal intolerance to calcium: 19.5%(8/41) vs. 21.1%(8/38)
| Nasal bleeding: 4.9%(2/41) vs. 0.0%(0/38)
| Nasal intolerance to spray: 2.4%(1/41) vs. 0.0%(0/38)
Reginster JY et al., 1995 ^232^ | Intranasal calcitonin 200iu vs. Intranasal calcitonin 50iu vs. Placebo:
| Epistaxis: 0.0%(0/84) vs. 0.0%(0/84) vs. 1.2%(1/83)
| Nasal irritation: 1.2%(1/84) vs. 0.0%(0/84) vs. 3.6%(3/83)
| Pancreatitis: 2.4%(2/84) vs. 0.0%(0/84) vs. 0.0%(0/83)
| Phlebitis: 0.0%(0/84) vs. 0.0%(0/84) vs. 2.4%(2/83)
| Rhinitis: 3.6%(3/84) vs. 0.0%(0/84) vs. 0.0%(0/83)
| Sneezing: 0.0%(0/84) vs. 1.2%(1/84) vs. 0.0%(0/83)
Reginster JY et al., 2003 ^233^ | Fluoride vs. Raloxifene+ Fluoride:
| Incidence of serious AE: 13.2%(39/296) vs. 17.7%(53/300)
| Vasodilatation (hot flashes): 3.7%(11/296) vs. 9.7%(29/300)
| Venous thromboembolism: 0.3%(1/296) vs. 0.0%(0/300)
Reginster JY et al., 2005 ^234^ | Ibandronate 100mg / 3 mo vs. Ibandronate 150mg / 3 mo vs. Ibandronate 50mg / 1 mo ; 100mg / 2 mo vs. Ibandronate 50mg / 3 mo vs. Placebo:
| Any AE: 91.7%(33/36) vs. 88.9%(32/36) vs. 94.4%(17/18) vs. 100.0%(18/18) vs. 94.4%(34/36)
| Any drug-related AE: 5.6%(2/36) vs. 5.6%(2/36) vs. 0.0%(0/18) vs. 16.7%(3/18) vs. 8.3%(3/36)
| Any serious AE: 0.0%(0/36) vs. 0.0%(0/36) vs. 0.0%(0/18) vs. 0.0%(0/18) vs. 0.0%(0/36)
| Death due to AE: 0.0%(0/36) vs. 0.0%(0/36) vs. 0.0%(0/18) vs. 0.0%(0/18) vs. 0.0%(0/36)
| Flu-like symptoms: 47.2%(17/36) vs. 44.4%(16/36) vs. 33.3%(6/18) vs. 44.4%(8/18) vs. 55.6%(20/36)
| Upper GI any time: 41.7%(15/36) vs. 41.7%(15/36) vs. 61.1%(11/18) vs. 16.7%(3/18) vs. 33.3%(12/36)
| Upper GI w/i 3d of treatment: 22.2%(8/36) vs. 25.0%(9/36) vs. 22.2%(4/18) vs. 0.0%(0/18) vs. 16.7%(6/36)
Reginster JY et al., 2006 ^235^ | Ibandronate 100mg vs. Ibandronate 150mg vs. Ibandronate 2.5mg vs. Ibandronate 50+50mg:
| Any AE: 79.1%(318/402) vs. 79.1%(317/401) vs. 75.1%(302/402) vs. 77.5%(313/404)
| Any drug-related AE: 35.6%(143/402) vs. 36.4%(146/401) vs. 31.8%(128/402) vs. 29.5%(119/404)
| Any serious AE: 13.7%(55/402) vs. 11.2%(45/401) vs. 9.5%(38/402) vs. 13.4%(54/404)
| Any serious drug-related AE: 0.7%(3/402) vs. 0.2%(1/401) vs. 0.5%(2/402) vs. 0.5%(2/404)
| Flu-like symptoms related to drug: 1.2%(5/402) vs. 3.2%(13/401) vs. 0.2%(1/402) vs. 1.0%(4/404)
| Upper GI AE: 25.4%(102/402) vs. 22.2%(89/401) vs. 22.4%(90/402) vs. 19.6%(79/404)
Reid DM et al., 2000 ^236^ | Risedronate 5mg vs. Risedronate 2.5mg vs. Placebo:
| Any clinical event: 97.0%(97/100) vs. 93.6%(88/94) vs. 95.8%(92/96)
| Abdominal pain: 13.0%(13/100) vs. 5.3%(5/94) vs. 10.4%(10/96)
| Arthralgia: 16.0%(16/100) vs. 0.0%(0/94) vs. 24.0%(23/96)
| Back pain: 10.0%(10/100) vs. 0.0%(0/94) vs. 23.0%(22/96)
| Drug related: 32.0%(32/100) vs. 27.7%(26/94) vs. 37.5%(36/96)
| Dyspepsia: 13.0%(13/100) vs. 5.3%(5/94) vs. 9.4%(9/96)
| Esophageal ulcer: 0.0%(0/100) vs. 1.1%(1/94) vs. 0.0%(0/96)
| Esophagitis: 1.0%(1/100) vs. 1.1%(1/94) vs. 0.0%(0/96)
| GI disorder: 4.0%(4/100) vs. 0.0%(0/94) vs. 0.0%(0/96)
| Gastritis: 1.0%(1/100) vs. 1.1%(1/94) vs. 2.1%(2/96)
| Serious event**: 37.0%(37/100) vs. 34.0%(32/94) vs. 38.5%(37/96)
| Stomach ulcer: 0.0%(0/100) vs. 2.1%(2/94) vs. 1.0%(1/96)
| UGI symptoms: 25.0%(25/100) vs. 14.9%(14/94) vs. 21.9%(21/96)
Reid IR et al., 1988 ^237^ | Pamidronate vs. Placebo:
| Death: 10.0%(2/20) vs. 0.0%(0/20)
| Duodenitis: 5.0%(1/20) vs. 0.0%(0/20)
| Epigastric discomfort: 0.0%(0/20) vs. 10.0%(2/20)
| Erosive gastritis: 0.0%(0/20) vs. 5.0%(1/20)
| Gastric ulceration: 5.0%(1/20) vs. 0.0%(0/20)
| Nausea: 30.0%(6/20) vs. 0.0%(0/20)
| Osteomalacia: 5.0%(1/20) vs. 0.0%(0/20)
Reid IR et al., 1994 ^238^ | Pamidronate vs. Placebo:
| Abdominal pain: 0.0%(0/31) vs. 3.3%(1/30)
| Blurred vision: 0.0%(0/31) vs. 3.3%(1/30)
| Death due to heart failure: 0.0%(0/31) vs. 3.3%(1/30)
| Duodenal ulcer: 3.2%(1/31) vs. 0.0%(0/30)
| Duodenitis: 0.0%(0/31) vs. 3.3%(1/30)
| Evidence of GI bleeding: 6.5%(2/31) vs. 6.7%(2/30)
| Gastrointestinal AEs: 48.4%(15/31) vs. 40.0%(12/30)
| Nausea: 22.6%(7/31) vs. 13.3%(4/30)
| Skin pain: 0.0%(0/31) vs. 3.3%(1/30)
Reid IR et al., 2002 ^239^ | Zoledronic acid 0.25 mg vs. Zoledronic acid 0.50 mg vs. Zoledronic acid 1 mg vs. Zoledronic acid 2 mg vs. Zoledronic acid 4 mg vs. Placebo:
| Any serious AE: 6.7%(4/60) vs. 6.9%(4/58) vs. 13.2%(7/53) vs. 8.2%(5/61) vs. 10.0%(6/60) vs. 5.1%(3/59)
| Arthralgia: 15.0%(9/60) vs. 13.8%(8/58) vs. 17.0%(9/53) vs. 24.6%(15/61) vs. 8.3%(5/60) vs. 15.3%(9/59)
| Influenza-like illness: 1.7%(1/60) vs. 6.9%(4/58) vs. 3.8%(2/53) vs. 16.4%(10/61) vs. 15.0%(9/60) vs. 6.8%(4/59)
| Iritis: 0.0%(0/60) vs. 0.0%(0/58) vs. 0.0%(0/53) vs. 0.0%(0/61) vs. 0.0%(0/60) vs. 0.0%(0/59)
| Myalgia: 20.0%(12/60) vs. 10.3%(6/58) vs. 13.2%(7/53) vs. 16.4%(10/61) vs. 10.0%(6/60) vs. 1.7%(1/59)
| Nausea: 5.0%(3/60) vs. 6.9%(4/58) vs. 9.4%(5/53) vs. 9.8%(6/61) vs. 13.3%(8/60) vs. 5.1%(3/59)
| Pyrexia: 10.0%(6/60) vs. 8.6%(5/58) vs. 13.2%(7/53) vs. 19.7%(12/61) vs. 15.0%(9/60) vs. 3.4%(2/59)
| Women with an adverse event: 86.7%(52/60) vs. 86.2%(50/58) vs. 94.3%(50/53) vs. 91.8%(56/61) vs. 90.0%(54/60) vs. 76.3%(45/59)
Reid IR et al., 2004 ^240^ | Estrogen 0.625mg/d vs. Raloxifene 150mg/d vs. Raloxifene 60mg/d vs. Placebo:
| Breast enlargement: 4.4%(7/158) vs. 0.6%(1/157) vs. 0.7%(1/152) vs. 0.7%(1/152)
| Breast pain: 15.8%(25/158) vs. 5.7%(9/157) vs. 7.2%(11/152) vs. 6.6%(10/152)
| Hernia: 0.6%(1/158) vs. 0.6%(1/157) vs. 3.3%(5/152) vs. 4.6%(7/152)
| Hot flashes: 10.8%(17/158) vs. 44.6%(70/157) vs. 33.6%(51/152) vs. 27.0%(41/152)
| Leg cramps: 3.2%(5/158) vs. 8.9%(14/157) vs. 9.9%(15/152) vs. 1.3%(2/152)
| MI: 0.6%(1/158) vs. 0.6%(1/157) vs. 0.7%(1/152) vs. 0.0%(0/152)
| Urinary incontinence: 7.0%(11/158) vs. 0.6%(1/157) vs. 0.7%(1/152) vs. 1.3%(2/152)
Rhee Y et al., 2006 ^241^ | Alfacalcidol vs. Maxmarvil:
| Abdominal pain: 2.1%(2/97) vs. 1.0%(1/102)
| Arthralgia: 0.0%(0/97) vs. 1.0%(1/102)
| Constipation or diarrhea: 2.1%(2/97) vs. 3.9%(4/102)
| Dizziness: 1.0%(1/97) vs. 2.0%(2/102)
| Dyspepsia: 13.4%(13/97) vs. 17.6%(18/102)
| Headache: 8.2%(8/97) vs. 3.9%(4/102)
| Nausea: 6.2%(6/97) vs. 5.9%(6/102)
| Other AE: 5.2%(5/97) vs. 2.0%(2/102)
Riis BJ et al., 2001 ^242^ | Ibandronate 2.5mg vs. Ibandronate 20mg vs. Placebo:
| Cardiovascular: 9.9%(8/81) vs. 10.3%(8/78) vs. 9.9%(8/81)
| Constipation: 6.2%(5/81) vs. 1.2%(1/78) vs. 0.0%(0/81)
| Death: 0.0%(0/81) vs. 1.0%(1/78) vs. 1.2%(1/81)
| Diarrhea: 11.1%(9/81) vs. 10.2%(8/78) vs. 1.2%(1/81)
| Endocrine: 2.2%(2/81) vs. 0.0%(0/78) vs. 1.1%(1/81)
| GI disorder: 0.0%(0/81) vs. 2.8%(2/78) vs. 6.2%(5/81)
| GI pain: 2.3%(2/81) vs. 5.1%(4/78) vs. 1.2%(1/81)
| Gastroenteritis: 3.9%(3/81) vs. 1.2%(1/78) vs. 2.8%(2/81)
| Hemic/lymphatic: 0.0%(0/81) vs. 1.2%(1/78) vs. 1.1%(1/81)
| Metabolic: 1.2%(1/81) vs. 5.1%(4/78) vs. 1.2%(1/81)
| Musculoskeletal: 24.0%(19/81) vs. 14.7%(11/78) vs. 24.0%(19/81)
| Nausea: 3.8%(3/81) vs. 6.7%(5/78) vs. 11.1%(9/81)
| Nervous system: 23.8%(19/81) vs. 18.0%(14/78) vs. 19.0%(15/81)
| Respiratory: 34.0%(28/81) vs. 33.0%(26/78) vs. 42.0%(34/81)
| Skin and appendages: 12.7%(10/81) vs. 1.0%(1/78) vs. 11.5%(9/81)
| Special senses: 7.3%(6/81) vs. 5.2%(4/78) vs. 5.0%(4/81)
| Urogenital: 7.0%(6/81) vs. 10.8%(8/78) vs. 13.0%(11/81)
| Vomiting: 3.8%(3/81) vs. 3.9%(3/78) vs. 2.7%(2/81)
Ringe JD et al., 2001 ^243^ | Alendronate vs. Vitamin D:
| Clinical AE: 38.2%(26/68) vs. 47.0%(31/66)
| Hypercalciuria: 4.4%(3/68) vs. 12.1%(8/66)
| Nephrolithiasis: 1.5%(1/68) vs. 4.5%(3/66)
Ringe JD et al., 2003 ^244^ | Ibandronate vs. Vitamin D:
| Acute-phase reaction: 1.9%(1/52) vs. 0.0%(0/52)
| Arthralgia/myalgia: 11.5%(6/52) vs. 7.7%(4/52)
| Constipation: 0.0%(0/52) vs. 3.8%(2/52)
| Diarrhea: 5.8%(3/52) vs. 1.9%(1/52)
| Epigastric pain: 9.6%(5/52) vs. 17.3%(9/52)
| Hypercalciuria/hypercalcemia: 1.9%(1/52) vs. 7.7%(4/52)
| Nausea: 5.8%(3/52) vs. 3.8%(2/52)
| Other: 3.8%(2/52) vs. 1.9%(1/52)
Ringe JD et al., 2003 ^245^ | Alendronate vs. Vitamin D:
| Acne: 1.5%(1/68) vs. 0.0%(0/66)
| Diarrhea/soft stools: 5.9%(4/68) vs. 4.5%(3/66)
| Epigastric pain: 14.7%(10/68) vs. 13.6%(9/66)
| Hypercalciuria: 4.4%(3/68) vs. 15.2%(10/66)
| Lower leg pain: 1.5%(1/68) vs. 3.0%(2/66)
| Meteorism: 2.9%(2/68) vs. 3.0%(2/66)
| Myalgia: 2.9%(2/68) vs. 1.5%(1/66)
| Nausea: 4.4%(3/68) vs. 3.0%(2/66)
| Obstipation: 5.9%(4/68) vs. 6.1%(4/66)
| Pruritus: 1.5%(1/68) vs. 3.0%(2/66)
| Renal calculi: 1.5%(1/68) vs. 4.5%(3/66)
| Retrosternal pain: 2.9%(2/68) vs. 1.5%(1/66)
Ringe JD et al., 2003 ^246^ | Ibandronate vs. Vitamin D:
| Arthralgia or myalgia: 13.8%(8/58) vs. 7.0%(4/57)
| Constipation: 1.7%(1/58) vs. 5.3%(3/57)
| Death due to AE: 6.9%(4/58) vs. 7.0%(4/57)
| Diarrhea: 5.2%(3/58) vs. 5.3%(3/57)
| Epigastric pain: 20.7%(12/58) vs. 21.1%(12/57)
| Hypercalciuria or hypercalcemia: 1.7%(1/58) vs. 8.8%(5/57)
| Nausea: 6.9%(4/58) vs. 5.3%(3/57)
| Other AE: 5.2%(3/58) vs. 3.5%(2/57)
| Other death: 0.0%(0/58) vs. 1.8%(1/57)
Ringe JD et al., 2005 ^247^ | Etidronate / 14 d & monofluorophosphate + CA + Vitamin D vs. Etidronate 400mg/d + CA + Vitamin D:
| Any AE: 46.2%(12/26) vs. 50.0%(13/26)
Ringe JD et al., 2006 ^248^ | Alfacalcidol 1 ug & calcium 500 mg & or Vitamin D 1000 iu & calcium 800 mg vs. Risedronate 5 mg & calcium 1000 mg & Vitamin D 800 iu:
| Back pain: 93.0%(147/158) vs. 68.0%(109/158)
Rizzoli R et al., 2002 ^249^ | Alendronate 10mg daily vs. Alendronate 35mg twice weekly vs. Alendronate 70mg weekly:
| Abdominal pain: 7.6%(28/370) vs. 7.9%(29/369) vs. 11.2%(58/519)
| Acid regurgitation: 4.9%(18/370) vs. 5.4%(20/369) vs. 4.6%(24/519)
| Dyspepsia: 6.5%(24/370) vs. 5.4%(20/369) vs. 6.6%(34/519)
| Nausea: 7.6%(28/370) vs. 6.8%(25/369) vs. 6.6%(34/519)
| Peptic ulcer perforations or bleeds: 1.4%(5/370) vs. 1.1%(4/369) vs. 0.6%(3/519)
| Upper GI symptoms: 30.0%(111/370) vs. 29.0%(107/369) vs. 29.3%(152/519)
Rosen CJ et al., 2005 ^250^ | Alendronate vs. Risedronate:
| Any AE: 75.8%(394/520) vs. 74.9%(399/533)
| Any UGI AE: 22.3%(116/520) vs. 19.9%(106/533)
| Clinical AE: 6.3%(33/520) vs. 6.2%(33/533)
| Dyspepsia: 8.2%(43/520) vs. 7.8%(42/533)
| GERD: 2.7%(14/520) vs. 3.0%(16/533)
| Serious AE: 8.7%(45/520) vs. 7.7%(41/533)
Rossini M et al., 2000 ^251^ | Alendronate 10mg(cyclical) vs. Alendronate 20 mg(once weekly) vs. Control:
| Moderate GI disturbance: 0.0%(0/42) vs. 7.3%(3/41) vs. 0.0%(0/41)
Rossouw JE et al., 2002 ^252^ | Estrogen+ Progesterone vs. Placebo:
| Adjudicated deaths: 2.5%(215/8506) vs. 2.5%(201/8102)
| Breast cancer - death: 0.0%(3/8506) vs. 0.0%(2/8102)
| Cardiovascular - death: 0.8%(65/8506) vs. 0.7%(55/8102)
| Colorectal cancer: 0.5%(45/8506) vs. 0.8%(67/8102)
| Coronary Heart Disease: 1.9%(164/8506) vs. 1.5%(122/8102)
| Coronary artery bypass grafting/Percutaneous transluminal coronary angina: 2.2%(183/8506) vs. 2.1%(171/8102)
| Death: 2.7%(231/8506) vs. 2.7%(218/8102)
| Endometrial cancer: 0.3%(22/8506) vs. 0.3%(25/8102)
| Invasive breast cancer: 2.0%(166/8506) vs. 1.5%(124/8102)
| Other cancer - death: 1.2%(104/8506) vs. 1.1%(86/8102)
| Other known cause - death: 0.4%(34/8506) vs. 0.5%(41/8102)
| Stroke: 1.5%(127/8506) vs. 1.0%(85/8102)
| Total deaths: 2.7%(231/8506) vs. 2.7%(218/8102)
| Unknown cause - death: 0.1%(9/8506) vs. 0.2%(17/8102)
| Venous thromboembolic disease: 1.8%(151/8506) vs. 0.8%(67/8102)
Roux C et al., 1998 ^253^ | Etidronate vs. Placebo:
| Abdominal pain: 17.0%(10/59) vs. 15.5%(9/58)
| Death: 5.1%(3/59) vs. 0.0%(0/58)
| Moderate UGI events: 11.9%(7/59) vs. 5.2%(3/58)
| Total patients reporting AEs: 86.0%(51/59) vs. 88.0%(51/58)
Rubin MR et al., 2003 ^254^ | Raloxifene vs. Control:
| Chest discomfort: 0.0%(0/9) vs. 11.1%(1/9)
Ryan PJ et al., 2000 ^255^ | Pamidronate 150 mg/day vs. Pamidronate 300 mg/day vs. Placebo:
| Abnormal liver function test: 0.0%(0/41) vs. 0.0%(0/40) vs. 2.4%(1/41)
| Ampicillin-type rash: 2.4%(1/41) vs. 0.0%(0/40) vs. 0.0%(0/41)
| Anemia: 2.4%(1/41) vs. 0.0%(0/40) vs. 2.4%(1/41)
| Back pain: 24.4%(10/41) vs. 25.0%(10/40) vs. 34.1%(14/41)
| Carcinoma of the bronchus: 0.0%(0/41) vs. 2.5%(1/40) vs. 0.0%(0/41)
| Diarrhea: 9.8%(4/41) vs. 10.0%(4/40) vs. 12.2%(5/41)
| Drug-related Back pain: 2.4%(1/41) vs. 12.5%(5/40) vs. 9.8%(4/41)
| Drug-related Diarrhea: 9.8%(4/41) vs. 10.0%(4/40) vs. 12.2%(5/41)
| Drug-related Head discomfort: 4.9%(2/41) vs. 10.0%(4/40) vs. 4.9%(2/41)
| Drug-related Heartburn: 2.4%(1/41) vs. 10.0%(4/40) vs. 0.0%(0/41)
| Drug-related Indigestion: 7.3%(3/41) vs. 15.0%(6/40) vs. 9.8%(4/41)
| Drug-related Nausea: 17.1%(7/41) vs. 30.0%(12/40) vs. 4.9%(2/41)
| Drug-related Vomiting: 9.8%(4/41) vs. 17.5%(7/40) vs. 0.0%(0/41)
| Head discomfort: 9.8%(4/41) vs. 20.0%(8/40) vs. 7.3%(3/41)
| Heartburn: 2.4%(1/41) vs. 10.0%(4/40) vs. 2.4%(1/41)
| Indigestion: 7.3%(3/41) vs. 15.0%(6/40) vs. 9.8%(4/41)
| Lymphatic leukemia: 0.0%(0/41) vs. 2.5%(1/40) vs. 0.0%(0/41)
| Multiple Myeloma: 2.4%(1/41) vs. 0.0%(0/40) vs. 0.0%(0/41)
| Nausea: 17.1%(7/41) vs. 35.0%(14/40) vs. 9.8%(4/41)
| Stroke: 2.4%(1/41) vs. 0.0%(0/40) vs. 0.0%(0/41)
| Vertebrobasilar insufficiency: 0.0%(0/41) vs. 2.5%(1/40) vs. 0.0%(0/41)
| Vomiting: 9.8%(4/41) vs. 17.5%(7/40) vs. 2.4%(1/41)
Saag KG et al., 1998 ^256^ | Alendronate 10mg vs. Alendronate 5mg vs. Placebo:
| Any AE: 83.4%(131/157) vs. 80.1%(129/161) vs. 79.2%(126/159)
| Abdominal pain: 9.6%(15/157) vs. 5.6%(9/161) vs. 5.0%(8/159)
| Any UGI AE: 25.5%(40/157) vs. 18.6%(30/161) vs. 16.4%(26/159)
| Any serious AE: 19.1%(30/157) vs. 15.5%(25/161) vs. 21.4%(34/159)
| Any serious GI AE: 1.3%(2/157) vs. 0.0%(0/161) vs. 1.3%(2/159)
| Esophageal irritation: 1.9%(3/157) vs. 3.1%(5/161) vs. 2.5%(4/159)
| Headache: 8.0%(13/157) vs. 8.0%(13/161) vs. 6.0%(10/159)
| Musculoskeletal pain: 16.0%(25/157) vs. 14.0%(23/161) vs. 16.0%(25/159)
| Peptic ulcer: 1.3%(2/157) vs. 0.6%(1/161) vs. 1.3%(2/159)
| UTI: 6.0%(9/157) vs. 10.0%(16/161) vs. 8.0%(13/159)
| Urinary: 13.0%(20/157) vs. 12.0%(19/161) vs. 9.0%(14/159)
Sahota O et al., 2000 ^257^ | Alendronate 10mg (continuous) vs. Alendronate 10mg (cyclical) vs. Calcitriol 250ng (twice a day) vs. Etidronate:
| Abdominal bloating: 0.0%(0/37) vs. 0.0%(0/33) vs. 2.9%(1/34) vs. 0.0%(0/36)
| Dyspeptic - confluent ulcerative esophagitis: 2.7%(1/37) vs. 0.0%(0/33) vs. 0.0%(0/34) vs. 0.0%(0/36)
| Dyspeptic side effects: 16.2%(6/37) vs. 0.0%(0/33) vs. 0.0%(0/34) vs. 0.0%(0/36)
| Mild/moderate esophagitis: 2.7%(1/37) vs. 0.0%(0/33) vs. 0.0%(0/34) vs. 0.0%(0/36)
| Nonspecific abdominal discomfort: 0.0%(0/37) vs. 3.0%(1/33) vs. 0.0%(0/34) vs. 0.0%(0/36)
Sambrook P et al., 1993 ^258^ | Calcitonin+ Calcium+ Vitamin D vs. Calcium vs. Calcium+ Vitamin D:
| GI symptoms: 24.1%(7/29) vs. 3.4%(1/29) vs. 17.6%(6/34)
| Headache: 3.4%(1/29) vs. 0.0%(0/29) vs. 2.9%(1/34)
| Hypercalcemia: 27.6%(8/29) vs. 3.4%(1/29) vs. 23.5%(8/34)
| Nasal symptoms: 31.0%(9/29) vs. 24.1%(7/29) vs. 26.5%(9/34)
| Rash: 6.9%(2/29) vs. 3.4%(1/29) vs. 5.9%(2/34)
Sambrook PN et al., 2003 ^259^ | Alendronate+ Calcium vs. Calcium+ Vitamin D vs. Vitamin D:
| Dyspepsia: 14.0%(9/64) vs. 13.0%(8/64) vs. 7.0%(5/67)
| Hypercalcemia: 0.0%(0/64) vs. 5.0%(3/64) vs. 7.0%(5/67)
Sambrook PN et al., 2004 ^260^ | Alendronate vs. Placebo:
| Esophagitis: 0.0%(0/55) vs. 3.4%(1/29)
| Peptic ulcer: 0.0%(0/55) vs. 3.4%(1/29)
| Upper GI: 0.0%(0/55) vs. 0.0%(0/29)
Sambrook PN et al., 2004 ^261^ | Alendronate vs. Raloxifene:
| Any AE: 62.6%(154/246) vs. 65.1%(157/241)
| Drug related AE: 22.8%(56/246) vs. 27.0%(65/241)
| Drug related UGI AE: 9.3%(23/246) vs. 16.2%(39/241)
| Drug related vasomotor AE: 2.4%(6/246) vs. 7.9%(19/241)
| Serious AE: 4.5%(11/246) vs. 5.8%(14/241)
| Sudden death of unknown etiology: 0.0%(0/246) vs. 0.4%(1/241)
| Upper GI AE: 15.4%(38/246) vs. 22.0%(53/241)
| Vasomotor AE: 3.7%(9/246) vs. 9.5%(23/241)
Sato S et al., 2003 ^262^ | Control vs. Etidronate:
| Facial rash: 0.0%(0/51) vs. 2.0%(1/51)
| Gastrointestinal: 0.0%(0/51) vs. 0.0%(0/51)
| Headache: 0.0%(0/51) vs. 2.0%(1/51)
Sato Y et al., 2000 ^263^ | Etidronate vs. Control vs. Placebo:
| Peptic ulcer: 2.0%(1/49) vs. 0.0%(0/40) vs. 0.0%(0/49)
Sato Y et al., 2004 ^264^ | Etidronate vs. Placebo:
| Peptic ulcer: 2.5%(1/40) vs. 0.0%(0/40)
Sato Y et al., 2005 ^265^ | Risedronate vs. Placebo:
| Abdominal pain: 0.7%(1/140) vs. 0.0%(0/140)
| Death or intercurrent illness: 0.7%(1/140) vs. 1.4%(2/140)
| Esophagitis: 1.4%(2/140) vs. 0.0%(0/140)
Sato Y et al., 2005 ^266^ | Risedronate vs. Control:
| Abdominal pain: 1.2%(3/250) vs. 0.0%(0/250)
| Death or intercurrent illness: 4.0%(10/250) vs. 4.0%(10/250)
| Epigastric discomfort and nausea: 0.0%(0/250) vs. 1.2%(3/250)
| Esophagitis: 0.4%(1/250) vs. 0.0%(0/250)
| Leukopenia: 0.8%(2/250) vs. 0.0%(0/250)
Sato Y et al., 2005 ^267^ | Risedronate 2.5mg vs. Placebo:
| Abdominal pain: 1.6%(3/187) vs. 0.0%(0/187)
| Esophagitis: 0.5%(1/187) vs. 0.0%(0/187)
| Leukopenia: 0.5%(1/187) vs. 0.0%(0/187)
Sato Y et al., 2006 ^268^ | Alendronate vs. Placebo:
| Abdominal pain: 0.0%(0/144) vs. 2.1%(3/144)
| Diarrhea: 2.1%(3/144) vs. 0.0%(0/144)
| Esophagitis: 1.4%(2/144) vs. 0.0%(0/144)
| Leukopenia: 0.7%(1/144) vs. 0.0%(0/144)
Sato Y et al., 2006 ^269^ | Etidronate vs. Placebo:
| Abdominal pain: 9.8%(4/41) vs. 0.0%(0/41)
| Anorexia: 0.0%(0/41) vs. 2.4%(1/41)
| Death or intercurrent illness: 2.4%(1/41) vs. 0.0%(0/41)
| Liver dysfunction: 0.0%(0/41) vs. 0.0%(0/41)
| Mechanical ventilation, artificial feeding, or death: 9.8%(4/41) vs. 7.3%(3/41)
| Renal dysfunction: 0.0%(0/41) vs. 0.0%(0/41)
Schwarz C et al., 2004 ^270^ | Zoledronic acid vs. Placebo:
| Biopsy-proven acute rejections (Banff 2a): 20.0%(2/10) vs. 30.0%(3/10)
| Clinically suspected but not biopsy-confirmed rejection: 10.0%(1/10) vs. 0.0%(0/10)
Shane E et al., 2004 ^271^ | Alendronate vs. Vitamin D:
| Abdominal pain: 13.5%(10/74) vs. 12.0%(9/75)
| Any GI effects: 59.5%(44/74) vs. 57.3%(43/75)
| Calcitriol dose reduced: 2.7%(2/74) vs. 5.3%(4/75)
| Creatinine clearance <= 30ml/min: 23.0%(17/74) vs. 30.7%(23/75)
| Death: 1.4%(1/74) vs. 6.7%(5/75)
| Heartburn or acid reflux: 6.8%(5/74) vs. 16.0%(12/75)
| Hemorrhage: 2.7%(2/74) vs. 1.3%(1/75)
| Hospitalization: 50.0%(37/74) vs. 46.7%(35/75)
| Hypercalcemia: 1.4%(1/74) vs. 8.0%(6/75)
| Hypercalciuria: 6.8%(5/74) vs. 26.7%(20/75)
| Infection: 32.4%(24/74) vs. 25.3%(19/75)
| Nausea: 28.4%(21/74) vs. 25.3%(19/75)
| Rejection>=Grade 3A: 18.9%(14/74) vs. 17.3%(13/75)
| Serum creatinine level >=3 mg/dl: 5.4%(4/74) vs. 9.3%(7/75)
| Severe Hypercalcemia (serum calcium level =12.2 mg/d): 0.0%(0/74) vs. 1.3%(1/75)
| Supplemental calcium dose reduced: 5.4%(4/74) vs. 16.0%(12/75)
Sharma RK et al., 2002 ^272^ | Alendronate vs. Control:
| Upper GI symptoms: 50.0%(3/6) vs. 0.0%(0/6)
Shimon I et al., 2005 ^273^ | Alendronate 10mg vs. Placebo / alendronate:
| Bacterial pneumonia: 0.0%(0/11) vs. 7.7%(1/13)
| Mild gastrointestinal complaints: 0.0%(0/11) vs. 7.7%(1/13)
Shiraki M et al., 1999 ^274^ | Alendronate vs. Vitamin D:
| Gastric ulcer: 1.0%(1/105) vs. 0.0%(0/105)
| Gastrointestinal symptoms: 19.0%(20/105) vs. 20.0%(21/105)
| No of AEs: 18.1%(19/105) vs. 23.8%(25/105)
| Other minor symptoms: 16.2%(17/105) vs. 18.1%(19/105)
Shiraki M et al., 2003 ^275^ | Risedronate 1mg vs. Risedronate 2.5mg vs. Risedronate 5mg vs. Placebo:
| Any AE: 21.2%(11/52) vs. 28.6%(14/49) vs. 30.4%(17/56) vs. 24.1%(13/54)
| Abnormal laboratory results: 13.5%(7/52) vs. 10.2%(5/49) vs. 12.5%(7/56) vs. 16.7%(9/54)
| Cardiac disturbances: 0.0%(0/52) vs. 0.0%(0/49) vs. 0.0%(0/56) vs. 3.7%(2/54)
| Constipation: 1.9%(1/52) vs. 0.0%(0/49) vs. 5.4%(3/56) vs. 1.9%(1/54)
| Diarrhea: 0.0%(0/52) vs. 0.0%(0/49) vs. 3.6%(2/56) vs. 0.0%(0/54)
| Disturbances of musculoskeletal, bone and connective tissues: 0.0%(0/52) vs. 2.0%(1/49) vs. 0.0%(0/56) vs. 1.9%(1/54)
| Disturbances of skin and subcutaneous tissues: 0.0%(0/52) vs. 0.0%(0/49) vs. 3.6%(2/56) vs. 0.0%(0/54)
| Drug related AE: 7.7%(4/52) vs. 22.4%(11/49) vs. 26.8%(15/56) vs. 18.5%(10/54)
| Epigastric pain: 1.9%(1/52) vs. 12.2%(6/49) vs. 7.1%(4/56) vs. 0.0%(0/54)
| GI disturbance: 0.0%(0/52) vs. 0.0%(0/49) vs. 1.8%(1/56) vs. 1.9%(1/54)
| Infectious and parasitic disease: 1.9%(1/52) vs. 0.0%(0/49) vs. 0.0%(0/56) vs. 0.0%(0/54)
| Metabolic and nutritional disturbances: 0.0%(0/52) vs. 2.0%(1/49) vs. 3.6%(2/56) vs. 1.9%(1/54)
| Nausea: 1.9%(1/52) vs. 8.2%(4/49) vs. 1.8%(1/56) vs. 0.0%(0/54)
| Neurological disturbances: 0.0%(0/52) vs. 2.0%(1/49) vs. 1.8%(1/56) vs. 0.0%(0/54)
| Serious adverse drug reaction: 0.0%(0/52) vs. 0.0%(0/49) vs. 0.0%(0/56) vs. 0.0%(0/54)
| Systemic and local disturbance: 0.0%(0/52) vs. 0.0%(0/49) vs. 0.0%(0/56) vs. 3.7%(2/54)
Siffledeen JS et al., 2005 ^276^ | Etidronate vs. Control:
| AE: 45.8%(33/72) vs. 35.2%(25/71)
Silberstein EB et al., 1992 ^277^ | Control vs. Etidronate:
| Transient nausea during phosphate therapy: 0.0%(0/20) vs. 7.1%(3/42)
Simon JA et al., 2002 ^278^ | Alendronate 10mg/day; then alendronate 70mg once a week vs. Alendronate 70mg once a week; then alendronate 10mg/day:
| Abdominal pain: 2.8%(4/145) vs. 0.0%(0/143)
| Constipation: 3.4%(5/145) vs. 2.1%(3/143)
| Diarrhea: 1.4%(2/145) vs. 6.3%(9/143)
| Epigastric discomfort: 2.8%(4/145) vs. 1.4%(2/143)
| Flatulence: 2.8%(4/145) vs. 0.7%(1/143)
| Heartburn: 2.8%(4/145) vs. 3.5%(5/143)
| Nausea: 3.4%(5/145) vs. 5.6%(8/143)
| Nonserious GI: 2.8%(4/145) vs. 1.4%(2/143)
Smith MR et al., 2001 ^279^ | GnRH vs. Pamidronate+ GnRH:
| Acute-phase reaction: 0.0%(0/22) vs. 14.3%(3/21)
| Anemia: 90.9%(20/22) vs. 90.5%(19/21)
| Angiosarcoma: 0.0%(0/22) vs. 4.8%(1/21)
| Fatigue: 36.4%(8/22) vs. 33.3%(7/21)
| Fevers: 0.0%(0/22) vs. 14.3%(3/21)
| Memory disorder: 0.0%(0/22) vs. 4.8%(1/21)
| Serious events*: 13.6%(3/22) vs. 23.8%(5/21)
| Transient arthralgias: 0.0%(0/22) vs. 14.3%(3/21)
| Weight gain > 5 kg: 13.6%(3/22) vs. 9.5%(2/21)
Smith MR et al., 2003 ^280^ | Zoledronic acid vs. Placebo:
| Arthralgia: 21.8%(12/55) vs. 13.7%(7/51)
| Back pain: 10.9%(6/55) vs. 5.9%(3/51)
| Constipation: 16.4%(9/55) vs. 15.7%(8/51)
| Death: 1.8%(1/55) vs. 0.0%(0/51)
| Dysuria: 12.7%(7/55) vs. 9.8%(5/51)
| Erectile dysfunction: 10.9%(6/55) vs. 9.8%(5/51)
| Fatigue: 38.2%(21/55) vs. 35.3%(18/51)
| Hematuria: 10.9%(6/55) vs. 0.0%(0/51)
| Hot flushes: 58.2%(32/55) vs. 51.0%(26/51)
| Nocturia: 16.4%(9/55) vs. 17.6%(9/51)
| Pain in limb: 12.7%(7/55) vs. 7.8%(4/51)
| Severe (grade 3 or 4) adverse events: 24.0%(13/55) vs. 39.0%(20/51)
| Urinary frequency: 14.5%(8/55) vs. 21.6%(11/51)
| Weakness: 12.7%(7/55) vs. 0.0%(0/51)
Smith MR et al., 2004 ^281^ | Raloxifene vs. Placebo:
| Advanced lung cancer: 0.0%(0/24) vs. 4.2%(1/24)
| Death: 4.2%(1/24) vs. 0.0%(0/24)
| Lung cancer diagnosis: 0.0%(0/24) vs. 4.2%(1/24)
| Progressive prostate cancer: 0.0%(0/24) vs. 4.2%(1/24)
| Pulmonary embolus: 4.2%(1/24) vs. 0.0%(0/24)
Snyder PJ et al., 1999 ^282^ | Placebo vs. Testosterone:
| Acute urinary retention: 0.0%(0/54) vs. 1.9%(1/54)
| Death: 3.7%(2/54) vs. 0.0%(0/54)
| Erythrocytosis: 0.0%(0/54) vs. 5.6%(3/54)
| Increase in residual urine volume: 1.9%(1/54) vs. 1.9%(1/54)
| Increase in respiratory distress index: 1.9%(1/54) vs. 1.9%(1/54)
| PSA increase persistent: 1.9%(1/54) vs. 5.6%(3/54)
| PSA increase transient: 11.1%(6/54) vs. 18.5%(10/54)
| Prostate cancer: 0.0%(0/54) vs. 1.9%(1/54)
| Prostate nodule: 1.9%(1/54) vs. 1.9%(1/54)
| Prostatitis: 1.9%(1/54) vs. 1.9%(1/54)
| Urosepsis: 1.9%(1/54) vs. 0.0%(0/54)
Stakkestad JA et al., 2003 ^283^ | Ibandronate 0.5 mg vs. Ibandronate 1 mg vs. Ibandronate 2 mg vs. Placebo:
| Musculoskeletal chest pain: 0.0%(0/157) vs. 0.6%(1/156) vs. 0.0%(0/158) vs. 0.0%(0/156)
| Myalgia: 14.0%(22/157) vs. 11.5%(18/156) vs. 21.5%(34/158) vs. 4.5%(7/156)
Stefanick ML et al., 2006 ^284^ | CEE vs. Placebo:
| In situ breast cancer: 0.5%(25/5310) vs. 0.6%(30/5429)
| Invasive breast cancer: 2.0%(104/5310) vs. 2.4%(133/5429)
Steiniche T et al., 1991 ^285^ | Etidronate vs. Etidronate+ Triiodothyronine:
| Diarrhea: 10.5%(2/19) vs. 0.0%(0/18)
Storm T et al., 1990 ^286^ | Etidronate vs. Placebo:
| Death: 15.2%(5/33) vs. 15.2%(5/33)
Storm T et al., 1996 ^287^ | Etidronate vs. Placebo:
| Death from MI: 5.9%(1/17) vs. 0.0%(0/20)
| General weakness, tiredness, and loss of appetite: 0.0%(0/17) vs. 5.0%(1/20)
Struys A et al., 1995 ^288^ | Calcium vs. Etidronate:
| Epigastric distress: 0.0%(0/20) vs. 5.3%(1/19)
Tanko LB et al., 2003 ^289^ | Ibandronate 30 min. before breakfast vs. Ibandronate 60 min. before breakfast:
| Any AE: 84.0%(80/95) vs. 69.0%(61/89)
| Dyspepsia: 3.7%(4/95) vs. 8.5%(8/89)
| Headache: 8.4%(8/95) vs. 6.6%(6/89)
| Serious AE: 5.6%(5/95) vs. 4.7%(4/89)
| Upper respiratory tract infection: 21.5%(20/95) vs. 17.9%(16/89)
Tanko LB et al., 2003 ^290^ | Ibandronate 10 mg vs. Ibandronate 20 mg vs. Ibandronate 5 mg vs. Placebo:
| Drug related AE: 9.0%(14/154) vs. 5.0%(8/159) vs. 10.0%(16/159) vs. 5.0%(8/158)
| Gastrointestinal AE: 5.0%(8/154) vs. 3.0%(5/159) vs. 6.0%(10/159) vs. 3.0%(5/158)
Tauchmanova L et al., 2003 ^291^ | Calcium & Vitamin D vs. Risedronate 5mg + calcium & Vitamin D:
| Arthralgia: 17.6%(3/17) vs. 23.5%(4/17)
| Mild back pain: 11.8%(2/17) vs. 17.6%(3/17)
Tauchmanova L et al., 2006 ^292^ | Calcium & Vitamin D vs. Estradiol + dihydroprogesterone + calcium & Vitamin D vs. Risedronate + calcium & Vitamin D vs. Zoledronic acid + calcium & Vitamin D:
| Breast tenderness: 0.0%(0/15) vs. 40.0%(6/15) vs. 0.0%(0/15) vs. 0.0%(0/15)
| Flu-like symptoms (inc. myalgia, body temp increase, nausea): 0.0%(0/15) vs. 0.0%(0/15) vs. 0.0%(0/15) vs. 80.0%(12/15)
| Mild to moderate gastric pain: 0.0%(0/15) vs. 0.0%(0/15) vs. 20.0%(3/15) vs. 0.0%(0/15)
| Moderate headache: 0.0%(0/15) vs. 33.3%(5/15) vs. 0.0%(0/15) vs. 0.0%(0/15)
Tekeoglu I et al., 2005 ^293^ | SCT nasal spray 200 iu everyday vs. SCT nasal spray 200 iu on 10 days consecutively per month vs. SCT nasal spray 200 iu on alternating 15 days per month:
| Local and temporary AEs - nasal burning or itching, rhinorrhea: 10.0%(4/40) vs. 5.0%(2/40) vs. 10.0%(4/40)
| Systemic AEs: 0.0%(0/40) vs. 0.0%(0/40) vs. 0.0%(0/40)
| Temporary nausea: 0.0%(0/40) vs. 0.0%(0/40) vs. 2.5%(1/40)
Terranova R et al., 1999 ^294^ | Etidronate+ Calcium vs. Placebo:
| Bruise: 3.1%(1/32) vs. 0.0%(0/19)
| Gastrointestinal: 3.1%(1/32) vs. 0.0%(0/19)
| Joint AE: 3.1%(1/32) vs. 0.0%(0/19)
| Polyuria: 3.1%(1/32) vs. 0.0%(0/19)
Thiebaud D et al., 1994 ^295^ | Fluoride vs. Pamidronate:
| Mild phlebitis: 0.0%(0/16) vs. 6.3%(1/16)
| Recurrence of fever: 0.0%(0/16) vs. 6.3%(1/16)
| Transient arthralgias: 31.3%(5/16) vs. 0.0%(0/16)
| Transient fever and rigors: 0.0%(0/16) vs. 6.3%(1/16)
| Transient fever with or without flu-like symptoms: 0.0%(0/16) vs. 31.3%(5/16)
| Transient nausea and mild gastric intolerances: 25.0%(4/16) vs. 0.0%(0/16)
Thiebaud D et al., 1997 ^296^ | Ibandronate 0.25mg vs. Ibandronate 0.5mg vs. Ibandronate 1.0mg vs. Ibandronate 2.0mg vs. Placebo:
| Any AE: 19.0%(19/24) vs. 21.0%(21/27) vs. 19.0%(19/26) vs. 19.0%(19/23) vs. 15.0%(15/26)
| Acute phase AEs: 1.0%(1/24) vs. 3.0%(3/27) vs. 1.0%(1/26) vs. 4.0%(4/23) vs. 0.0%(0/26)
| Gastrointestinal AE's: 6.0%(6/24) vs. 6.0%(6/27) vs. 7.0%(7/26) vs. 3.0%(3/23) vs. 4.0%(4/26)
Tiras MB et al., 2000 ^297^ | Calcitonin vs. Calcitonin+ Clodronate vs. Clodronate vs. Estrogen+ Progesterone:
| Gastrointestinal complaint: 0.0%(0/25) vs. 8.0%(2/25) vs. 4.0%(1/25) vs. 0.0%(0/25)
| Mastalgia: 0.0%(0/25) vs. 0.0%(0/25) vs. 0.0%(0/25) vs. 8.0%(2/25)
| Menorrhagia: 0.0%(0/25) vs. 0.0%(0/25) vs. 0.0%(0/25) vs. 4.0%(1/25)
| Severe headache: 0.0%(0/25) vs. 0.0%(0/25) vs. 0.0%(0/25) vs. 4.0%(1/25)
Tiras MB et al., 2000 ^298^ | Alendronate vs. Alendronate+ Estrogen vs. Estrogen:
| Epigastric pain: 2.5%(1/40) vs. 2.5%(1/40) vs. 0.0%(0/40)
| Heavy uterine bleeding: 0.0%(0/40) vs. 2.5%(1/40) vs. 2.5%(1/40)
Tonino RP et al., 2000 ^299^ | Alendronate 10mg vs. Alendronate 5mg vs. Placebo:
| Any AE: 91.0%(111/122) vs. 85.0%(96/113) vs. 90.4%(104/115)
| Drug-related AE: 10.7%(13/122) vs. 8.0%(9/113) vs. 13.0%(15/115)
| Serious AE: 12.3%(15/122) vs. 11.5%(13/113) vs. 11.3%(13/115)
| Serious drug-related AE: 0.8%(1/122) vs. 0.0%(0/113) vs. 0.0%(0/115)
| UGI AE: 17.2%(21/122) vs. 15.9%(18/113) vs. 18.3%(21/115)
| UGI AE drug related: 7.4%(9/122) vs. 4.4%(5/113) vs. 9.6%(11/115)
Torregrosa JV et al., 2003 ^300^ | Alendronate vs. Control:
| Minimal abdominal discomfort: 80.0%(11/14) vs. 0.0%(0/12)
Tucci JR et al., 1996 ^301^ | Alendronate 10mg vs. Alendronate 20/5mg vs. Alendronate 5mg vs. Placebo:
| Abdominal pain: 20.2%(19/94) vs. 18.1%(17/94) vs. 15.3%(15/98) vs. 10.9%(21/192)
| Drug related AE: 26.6%(25/94) vs. 30.9%(29/94) vs. 25.5%(25/98) vs. 21.9%(42/192)
| Drug related UGI AE: 16.0%(15/94) vs. 20.2%(19/94) vs. 16.3%(16/98) vs. 12.5%(24/192)
| Hypocalcemia (mild- none less than 8.0 mg/dl): 3.3%(3/94) vs. 0.0%(0/94) vs. 3.1%(3/98) vs. 0.0%(0/192)
| One or more AE: 94.7%(89/94) vs. 93.6%(88/94) vs. 93.9%(92/98) vs. 94.3%(181/192)
| One or more UGI AE: 52.1%(49/94) vs. 41.5%(39/94) vs. 35.7%(35/98) vs. 41.1%(79/192)
| Serious AE: 21.3%(20/94) vs. 14.9%(14/94) vs. 12.2%(12/98) vs. 18.2%(35/192)
| Serious UGI AE: 0.0%(0/94) vs. 2.1%(2/94) vs. 2.0%(2/98) vs. 1.0%(2/192)
| Stomach pain / hiatal hernia: 0.0%(0/94) vs. 1.1%(1/94) vs. 0.0%(0/98) vs. 0.0%(0/192)
Uchida S et al., 2005 ^302^ | Alendronate 35mg / weekly vs. Alendronate 5mg / day:
| Aggravation of allergic bowel syndrome: 0.0%(0/168) vs. 0.6%(1/160)
| Clinical AE: 85.1%(143/168) vs. 89.7%(140/160)
| Drug-related clinical AE: 13.1%(22/168) vs. 17.9%(28/160)
| Reflux esophagitis - drug-related: 0.0%(0/168) vs. 0.6%(1/160)
| Serious AE: 6.5%(11/168) vs. 4.4%(7/160)
| Upper gastrointestinal AEs: 10.7%(18/168) vs. 8.8%(14/160)
Ushiroyama T et al., 2001 ^303^ | Calcitonin vs. Calcitonin+ Vitamin D vs. Vitamin D vs. Placebo:
| Any other abnormal signs or clinical symptoms: 0.0%(0/49) vs. 0.0%(0/51) vs. 0.0%(0/50) vs. 0.0%(0/52)
| Hypercalcemia: 0.0%(0/49) vs. 0.0%(0/51) vs. 0.0%(0/50) vs. 0.0%(0/52)
| Throat discomfort: 14.3%(7/49) vs. 17.6%(9/51) vs. 0.0%(0/50) vs. 0.0%(0/52)
Uusi-Rasi K et al., 2003 ^304^ | Alendronate vs. Control:
| Abdominal pain: 0.0%(0/82) vs. 3.7%(3/82)
| Mild allergic-type skin reaction: 1.2%(1/82) vs. 0.0%(0/82)
| Severe abdominal pain w/ suspicion of GI bleeding: 0.0%(0/82) vs. 1.2%(1/82)
| Upper gastrointestinal symptom: 19.5%(16/82) vs. 32.9%(27/82)
Vogel VG et al., 2006 ^305^ | Raloxifene vs. Tamoxifen:
| Bone/cartilage/connective tissue cancer: 0.0%(2/9875) vs. 0.0%(3/9872)
| Buckle cavity and pharynx cancer: 0.0%(3/9875) vs. 0.0%(4/9872)
| Cancer of the esophagus: 0.0%(0/9875) vs. 0.0%(1/9872)
| Cancer of the spleen: 0.0%(1/9875) vs. 0.0%(0/9872)
| Colorectal cancer: 0.3%(30/9875) vs. 0.3%(31/9872)
| Eye: 0.0%(1/9875) vs. 0.0%(0/9872)
| Gallbladder cancer: 0.0%(1/9875) vs. 0.0%(1/9872)
| Gynecologic: cervix: 0.0%(0/9875) vs. 0.0%(1/9872)
| Gynecologic: other: 0.0%(2/9875) vs. 0.0%(1/9872)
| Gynecologic: ovary: 0.2%(18/9875) vs. 0.1%(12/9872)
| Kidney: 0.1%(13/9875) vs. 0.1%(9/9872)
| Leukemia or other lymphatic/hematopoietic: 0.3%(28/9875) vs. 0.3%(32/9872)
| Liver cancer: 0.0%(1/9875) vs. 0.0%(4/9872)
| Lung, trachea, bronchus cancer: 0.4%(39/9875) vs. 0.3%(28/9872)
| Nasal/middle ear/sinus cancer: 0.0%(1/9875) vs. 0.0%(1/9872)
| Nervous system: 0.1%(7/9875) vs. 0.1%(6/9872)
| Pancreas cancer: 0.1%(5/9875) vs. 0.1%(6/9872)
| Retroperitoneum cancer: 0.0%(1/9875) vs. 0.0%(4/9872)
| Secondary/uncertain: 0.0%(2/9875) vs. 0.0%(4/9872)
| Skin cancer: 0.1%(12/9875) vs. 0.1%(14/9872)
| Stomach cancer: 0.0%(1/9875) vs. 0.0%(3/9872)
| Thyroid gland: 0.2%(18/9875) vs. 0.1%(8/9872)
Wang C et al., 2004 ^306^ | Androgel 10g vs. Androgel 5.0g vs. Androgel 7.5g:
| Application site skin reaction: 10.3%(4/39) vs. 8.1%(5/62) vs. 13.6%(3/22)
| Prostate problem: 5.1%(2/39) vs. 1.6%(1/62) vs. 9.1%(2/22)
Wasnich RD et al., 2004 ^307^ | Alendronate 5mg for 2 yrs followed by 4yrs placebo vs. Alendronate 5mg for 4 yrs followed by 2 yrs placebo vs. Open label estrogen/progestin for 4yrs followed by 2yrs off therapy vs. Placebo:
| At least one drug-related AE: 0.0%(0/165) vs. 11.1%(18/165) vs. 88.2%(97/110) vs. 13.0%(33/252)
| Breast pain: 0.0%(0/165) vs. 0.0%(0/165) vs. 25.5%(28/110) vs. 0.0%(0/252)
| Menopause disorder: 0.0%(0/165) vs. 0.0%(0/165) vs. 48.2%(53/110) vs. 0.0%(0/252)
| Menstruation disorder: 0.0%(0/165) vs. 0.0%(0/165) vs. 53.6%(59/110) vs. 0.0%(0/252)
| Urogenital system disorders: 0.0%(0/165) vs. 0.0%(0/165) vs. 87.3%(96/110) vs. 0.0%(0/252)
Wassertheil-Smoller S et al., 2003 ^308^ | Estrogen with progestin vs. Placebo:
| Hemorrhagic stroke - intraparenchymal: 0.2%(13/8506) vs. 0.2%(14/8102)
| Hemorrhagic stroke - other or unspecified intracranial: 0.0%(0/8506) vs. 1.0%(81/8102)
| Hemorrhagic stroke - subarachnoid: 5.0%(425/8506) vs. 5.0%(405/8102)
| Ischemic stroke: 1.5%(125/8506) vs. 1.0%(81/8102)
| Other stroke: 0.0%(2/8506) vs. 0.0%(1/8102)
| Report of cerebrovascular death only: 0.1%(6/8506) vs. 0.1%(5/8102)
Weinstein RS et al., 2003 ^309^ | Estrogen vs. Raloxifene vs. Placebo:
| Adverse event: 39.0%(9/23) vs. 20.0%(4/20) vs. 13.0%(3/23)
Wimalawansa SJ, 1995 ^310^ | Control+ Calcium vs. Estrogen vs. Estrogen+ Etidronate vs. Etidronate:
| Breast tenderness: 0.0%(0/14) vs. 66.7%(10/15) vs. 0.0%(0/15) vs. 0.0%(0/14)
| Carcinoma of the ovary: 7.1%(1/14) vs. 0.0%(0/15) vs. 0.0%(0/15) vs. 0.0%(0/14)
| Cerebrovascular accident: 7.1%(1/14) vs. 0.0%(0/15) vs. 0.0%(0/15) vs. 0.0%(0/14)
| Hepatitis B: 0.0%(0/14) vs. 0.0%(0/15) vs. 6.7%(1/15) vs. 0.0%(0/14)
| Inability to tolerate medicine: 7.1%(1/14) vs. 13.3%(2/15) vs. 6.7%(1/15) vs. 14.3%(2/14)
| Menstrual bleeding: 0.0%(0/14) vs. 100.0%(15/15) vs. 0.0%(0/15) vs. 0.0%(0/14)
| Nausea initially: 0.0%(0/14) vs. 0.0%(0/15) vs. 0.0%(0/15) vs. 21.4%(3/14)
| Osteomalacia: 0.0%(0/14) vs. 0.0%(0/15) vs. 0.0%(0/15) vs. 21.4%(3/14)
Wimalawansa SJ, 1998 ^311^ | Control vs. Estrogen vs. Estrogen+ Etidronate vs. Etidronate:
| Death due to myocardial infarction: 0.0%(0/18) vs. 0.0%(0/18) vs. 0.0%(0/19) vs. 5.9%(1/17)
| Estrogen-related adverse effects: 0.0%(0/18) vs. 16.7%(3/18) vs. 10.5%(2/19) vs. 0.0%(0/17)
| Nausea: 0.0%(0/18) vs. 0.0%(0/18) vs. 0.0%(0/19) vs. 35.3%(6/17)
Worth H et al., 1994 ^312^ | Etidronate+ Vitamin D vs. Control:
| Exacerbation of underlying disease: 0.0%(0/20) vs. 5.0%(1/20)
| Nausea: 15.0%(3/20) vs. 0.0%(0/20)
Yang TS et al., 1998 ^313^ | Alendronate vs. Placebo:
| Climacteric syndrome: 3.3%(1/30) vs. 3.3%(1/30)
| Common cold: 3.3%(1/30) vs. 0.0%(0/30)
| Constipation: 0.0%(0/30) vs. 0.0%(0/30)
| Diarrhea: 0.0%(0/30) vs. 0.0%(0/30)
| Dyspepsia: 0.0%(0/30) vs. 0.0%(0/30)
| Dysphasia: 0.0%(0/30) vs. 0.0%(0/30)
| Esophageal ulcer: 0.0%(0/30) vs. 0.0%(0/30)
| Flatulence: 0.0%(0/30) vs. 0.0%(0/30)
| Hot flush, dry mouth (climacteric syndrome): 0.0%(0/30) vs. 3.3%(1/30)
| Menstrual bleeding: 3.3%(1/30) vs. 3.3%(1/30)
| Palpitation, fatigue (climacteric syndrome): 3.3%(1/30) vs. 0.0%(0/30)
| Unspecified GI: 6.7%(2/30) vs. 3.3%(1/30)
| Unspecified GI discomfort: 6.6%(2/30) vs. 3.3%(1/30)
Zegels B et al., 2001 ^314^ | Placebo vs. Risedronate followed by Calcium vs. Risedronate followed by Calcium followed by Risedronate followed by Calcium vs. Risedronate followed by placebo:
| Fatigue: 0.0%(0/8) vs. 0.0%(0/8) vs. 0.0%(0/8) vs. 12.5%(1/8)
| Flu and bronchitis: 0.0%(0/8) vs. 0.0%(0/8) vs. 0.0%(0/8) vs. 12.5%(1/8)
| Moderate-to-severe upper gastrointestinal adverse events: 0.0%(0/8) vs. 0.0%(0/8) vs. 0.0%(0/8) vs. 0.0%(0/8)
| Myocardial infarction: 12.5%(1/8) vs. 0.0%(0/8) vs. 0.0%(0/8) vs. 0.0%(0/8)
Zehnder Y et al., 2004 ^315^ | Alendronate+ Calcium vs. Control+Calcium:
| Chronic headache: 3.0%(1/33) vs. 0.0%(0/32)
| Diarrhea: 3.0%(1/33) vs. 3.1%(1/32)
| Dizziness: 3.0%(1/33) vs. 0.0%(0/32)
| Gastrointestinal adverse events: 12.1%(4/33) vs. 12.5%(4/32)
| Neurological adverse events: 6.1%(2/33) vs. 0.0%(0/32)
| Obstipation: 3.0%(1/33) vs. 3.1%(1/32)
| Pyrosis: 3.0%(1/33) vs. 6.3%(2/32)
| Syringomyelia: 0.0%(0/33) vs. 3.1%(1/32)
| Transitory retrosternal pain: 3.0%(1/33) vs. 0.0%(0/32)
Zein CO et al., 2005 ^316^ | Alendronate vs. Placebo:
| Abdominal distention: 5.9%(1/17) vs. 0.0%(0/17)
| Abdominal pain: 5.9%(1/17) vs. 11.8%(2/17)
| Any GI AE: 17.6%(3/17) vs. 17.6%(3/17)
| Flatulence: 0.0%(0/17) vs. 5.9%(1/17)
| Heartburn: 5.9%(1/17) vs. 0.0%(0/17)
| Musculoskeletal bone or joint pain: 6.0%(1/17) vs. 0.0%(0/17)
| Nausea: 0.0%(0/17) vs. 11.8%(2/17)
Zheng S et al., 2003 ^317^ | Raloxifene vs. Placebo:
| Angina pectoris: 0.0%(0/102) vs. 1.0%(1/102)
| Cardiac neurosis: 1.0%(1/102) vs. 0.0%(0/102)
| Deep venous thrombosis: 0.0%(0/102) vs. 0.0%(0/102)
| Endometrial carcinoma: 1.0%(1/102) vs. 0.0%(0/102)
| Enlarged uterine fibroids: 1.0%(1/102) vs. 0.0%(0/102)
| Flushes: 12.7%(13/102) vs. 7.8%(8/102)
| Leg cramps: 12.7%(13/102) vs. 7.8%(8/102)
| One or more serious adverse effect: 3.9%(4/102) vs. 1.0%(1/102)
| Vertebrobasilar blood supply insufficiency: 1.0%(1/102) vs. 0.0%(0/102)
Zheng SR et al., 2003 ^318^ | Raloxifene vs. Placebo:
| Adverse event: 2.9%(3/102) vs. 2.0%(2/102)
van Staa T et al., 1997 ^319^ | Etidronate vs. Nonosteoporosis control vs. Osteoporosis control:
| Abdominal pain: 7.6%(609/7977) vs. 4.6%(370/7977) vs. 7.3%(586/7977)
| Abdominal pain during NSAID use: 1.1%(88/7977) vs. 0.4%(32/7977) vs. 0.8%(67/7977)
| Abdominal pain during aspirin use: 0.3%(22/7977) vs. 0.3%(25/7977) vs. 0.5%(43/7977)
| Abdominal pain during corticosteroid use: 0.9%(68/7977) vs. 0.1%(5/7977) vs. 0.7%(54/7977)
| Esophagitis/esophageal ulcers: 1.6%(126/7977) vs. 1.0%(78/7977) vs. 1.4%(112/7977)
| Gastritis/duodenitis: 1.6%(125/7977) vs. 0.8%(64/7977) vs. 1.2%(99/7977)
| Gastrointestinal hemorrhage: 0.6%(49/7977) vs. 0.4%(31/7977) vs. 0.7%(56/7977)
| Peptic ulcers: 0.9%(72/7977) vs. 0.5%(38/7977) vs. 0.8%(61/7977)
| UGI AE: 3.8%(303/7977) vs. 2.2%(173/7977) vs. 3.2%(256/7977)
| UGI AE during aspirin use: 0.1%(11/7977) vs. 0.1%(8/7977) vs. 0.1%(10/7977)
| UGI AE during corticosteroid use: 0.4%(33/7977) vs. 0.1%(7/7977) vs. 0.2%(19/7977)
| Upper GI event during NSAID use: 0.5%(41/7977) vs. 0.1%(9/7977) vs. 0.5%(39/7977)
van der Poest Clement E et al., 200 ^320^ | Alendronate vs. Placebo:
| Serious adverse event: 4.8%(1/21) vs. 0.0%(0/20)
von Tirpitz C et al., 2003 ^321^ | Calcium+ Vitamin D vs. Calcium+ Vitamin D+ Fluoride vs. Ibandronate+ Calcium+ Vitamin D:
| AE: 23.1%(3/13) vs. 30.6%(11/36) vs. 25.7%(9/35)
| Bone pain: 0.0%(0/13) vs. 0.0%(0/36) vs. 5.7%(2/35)
| Testicular cancer: 0.0%(0/13) vs. 2.8%(1/36) vs. 0.0%(0/35)
| Undigested pills in feces: 0.0%(0/13) vs. 5.6%(2/36) vs. 0.0%(0/35)

Drugs: CEE=Conjugated Equine Estrogen, PTH=Parathyroid Hormone AEs: MI=Myocardial Infarction, UTI=Urinary Tract Infection, GI=Gastrointestinal

### Reference List for Evidence Table C1

1 Abellan PM, Bayina GFJ, Calabozo M, et al. (1995). Multicentric comparative study of synthetic salmon calcitonin nasally administered in the treatment of established postmenopausic osteoporosis. Anales De Medicina Interna.
2 Adachi JD, Bensen WG, Brown J, et al. (1997). Intermittent etidronate therapy to prevent corticosteroid-induced osteoporosis. N Engl J Med.
3 Adachi JD, Bensen WG, Bell MJ, et al. (1997). Salmon calcitonin nasal spray in the prevention of corticosteroid-induced osteoporosis. Br J Rheumatol.
4 Adachi JD, Adami S, Miller PD, et al. (2001). Tolerability of risedronate in postmenopausal women intolerant of alendronate. Aging (Milano).
5 Adachi JD, Saag KG, Delmas PD, et al. (2001). Two-year effects of alendronate on bone mineral density and vertebral fracture in patients receiving glucocorticoids: a randomized, double-blind, placebo-controlled extension trial. Arthritis Rheum.
6 Adami S, Baroni MC, Broggini M, et al. (1993). Treatment of postmenopausal osteoporosis with continuous daily oral alendronate in comparison with either placebo or intranasal salmon calcitonin. Osteoporos Int.
7 Adami S, Passeri M, Ortolani S, et al. (1995). Effects of oral alendronate and intranasal salmon calcitonin on bone mass and biochemical markers of bone turnover in postmenopausal women with osteoporosis. Bone.
8 Adami S, Bruni V, Bianchini D, et al. (2000). Prevention of early postmenopausal bone loss with cyclical etidronate. J Endocrinol Invest.
9 Adami S, Felsenberg D, Christiansen C, et al. (2004). Efficacy and safety of ibandronate given by intravenous injection once every 3 months. Bone.
10 Agrawal S, Krueger DC, Engelke JA, et al. (2006). Between-meal risedronate does not alter bone turnover in nursing home residents. J Am Geriatr Soc.
11 Alexandersen P, Riis BJ, Christiansen C. (1999). Monofluorophosphate combined with hormone replacement therapy induces a synergistic effect on bone mass by dissociating bone formation and resorption in postmenopausal women: a randomized study. J Clin Endocrinol Metab.
12 Amory JK, Watts NB, Easley KA, et al. (2004). Exogenous testosterone or testosterone with finasteride increases bone mineral density in older men with low serum testosterone. The Journal of clinical endocrinology and metabolism.
13 Anderson GL, Judd HL, Kaunitz AM, et al. (2003). Effects of estrogen plus progestin on gynecologic cancers and associated diagnostic procedures: the Women's Health Initiative randomized trial. JAMA.
14 Anderson GL, Limacher M, Assaf AR, et al. (2004). Effects of conjugated equine estrogen in postmenopausal women with hysterectomy: the Women's Health Initiative randomized controlled trial. JAMA.
15 Aris RM, Lester GE, Renner JB, et al. (2000). Efficacy of pamidronate for osteoporosis in patients with cystic fibrosis following lung transplantation. American journal of respiratory and critical care medicine.
16 Aris RM, Lester GE, Caminiti M, et al. (2004). Efficacy of alendronate in adults with cystic fibrosis with low bone density. Am J Respir Crit Care Med.
17 Ascott-Evans BH, Guanabens N, Kivinen S, et al. (2003). Alendronate prevents loss of bone density associated with discontinuation of hormone replacement therapy: a randomized controlled trial. Arch Intern Med.
18 Barrett-Connor E, Grady D, Sashegyi A, et al. (2002). Raloxifene and cardiovascular events in osteoporotic postmenopausal women: four-year results from the MORE (Multiple Outcomes of Raloxifene Evaluation) randomized trial. JAMA.
19 Bartram SA, Peaston RT, Rawlings DJ, et al. (2003). A randomized controlled trial of calcium with vitamin D, alone or in combination with intravenous pamidronate, for the treatment of low bone mineral density associated with Crohn's disease. Alimentary Pharmacology & Therapeutics.
20 Bauer DC, Black D, Ensrud K, et al. (2000). Upper gastrointestinal tract safety profile of alendronate: the fracture intervention trial. Arch Intern Med.
21 Baum M, Budzar AU, Cuzick J, et al. (2002). Anastrozole alone or in combination with tamoxifen versus tamoxifen alone for adjuvant treatment of postmenopausal women with early breast cancer: first results of the ATAC randomised trial. Lancet.
22 Bekker PJ, Holloway DL, Rasmussen AS, et al. (2004). A single-dose placebo-controlled study of AMG 162, a fully human monoclonal antibody to RANKL, in postmenopausal women. Journal of bone and mineral research : the official journal of the American Society for Bone and Mineral Research.
23 Bell NH, Bilezikian JP, Bone HG, et al. (2002). Alendronate increases bone mass and reduces bone markers in postmenopausal African-American women. The Journal of clinical endocrinology and metabolism.
24 Black DM, Cummings SR, Karpf DB, et al. (1996). Randomised trial of effect of alendronate on risk of fracture in women with existing vertebral fractures. Fracture Intervention Trial Research Group. Lancet.
25 Black DM, Delmas PD, Eastell R, et al. (2007). Once-yearly zoledronic acid for treatment of postmenopausal osteoporosis. N Engl J Med.
26 Blumel JE, Castelo-Branco C, de la Cuadra G, et al. (2003). Alendronate daily, weekly in conventional tablets and weekly in enteric tablets: preliminary study on the effects in bone turnover markers and incidence of side effects. Journal of obstetrics and gynaecology (Tokyo, Japan).
27 Body JJ, Gaich GA, Scheele WH, et al. (2002). A randomized double-blind trial to compare the efficacy of teriparatide. J Clin Endocrinol Metab.
28 Bone HG, Downs RW, Tucci JR, et al. (1997). Dose-response relationships for alendronate treatment in osteoporotic elderly women. Alendronate Elderly Osteoporosis Study Centers. J Clin Endocrinol Metab.
29 Bone HG, Greenspan SL, McKeever C, et al. (2000). Alendronate and estrogen effects in postmenopausal women with low bone mineral density. Alendronate/Estrogen Study Group. J Clin Endocrinol Metab.
30 Bone HG, Hosking D, Devogelaer JP, et al. (2004). Ten years' experience with alendronate for osteoporosis in postmenopausal women. N Engl J Med.
31 Bonnick S, Saag KG, Kiel DP, et al. Comparison of Weekly Treatment of Postmenopausal Osteoporosis with Alendronate versus Risedronate Over Two Years. J Clin Endocrinol Metab 2006.
32 Boutsen Y, Jamart J, Esselinckx W, et al. (1997). Primary prevention of glucocorticoid-induced osteoporosis with intermittent intravenous pamidronate: a randomized trial. Calcif Tissue Int.
33 Brown JP, Olszynski WP, Hodsman A, et al. (2001). Positive effect of etidronate therapy is maintained after drug is terminated in patients using corticosteroids. Journal of clinical densitometry : the official journal of the International Society for Clinical Densitometry.
34 Brown JP, Kendler DL, McClung MR, et al. (2002). The efficacy and tolerability of risedronate once a week for the treatment of postmenopausal osteoporosis. Calcif Tissue Int.
35 Brumsen C, Papapoulos SE, Lips P, et al. (2002). Daily oral pamidronate in women and men with osteoporosis: a 3-year randomized placebo-controlled clinical trial with a 2-year open extension. J Bone Miner Res.
36 Campbell IA, Douglas JG, Francis RM, et al. (2004). Five year study of etidronate and/or calcium as prevention and treatment for osteoporosis and fractures in patients with asthma receiving long term oral and/or inhaled glucocorticoids. Thorax.
37 Chailurkit LO, Jongjaroenprasert W, Rungbunnapun S, et al. (2003). Effect of alendronate on bone mineral density and bone turnover in Thai postmenopausal osteoporosis. Journal of bone and mineral metabolism.
38 Chen M, C S. (2001). Additive effect of alfacalcidol on bone mineral density of the lumbar spine in Taiwanese postmenopausal women treated with hormone replacement therapy and calcium supplementation: a randomized 2-year study. Clinical endocrinology.
39 Cherry N, Gilmour K, Hannaford P, et al. (2002). Oestrogen therapy for prevention of reinfarction in postmenopausal women: a randomised placebo controlled trial. Lancet.
40 Chesnut CH, McClung MR, Ensrud KE, et al. (1995). Alendronate treatment of the postmenopausal osteoporotic woman: effect of multiple dosages on bone mass and bone remodeling. The American journal of medicine.
41 Chesnut CH, Silverman S, Andriano K, et al. (2000). A randomized trial of nasal spray salmon calcitonin in postmenopausal women with established osteoporosis: the prevent recurrence of osteoporotic fractures study. PROOF Study Group. Am J Med.
42 Chesnut CH, Skag A, Christiansen C, et al. (2004). Effects of oral ibandronate administered daily or intermittently on fracture risk in postmenopausal osteoporosis. Journal of bone and mineral research : the official journal of the American Society for Bone and Mineral Research.
43 Chlebowski RT, Hendrix SL, Langer RD, et al. (2003). Influence of estrogen plus progestin on breast cancer and mammography in healthy postmenopausal women: the Women's Health Initiative Randomized Trial. JAMA.
44 Chlebowski RT, Wactawski-Wende J, Ritenbaugh C, et al. (2004). Estrogen plus progestin and colorectal cancer in postmenopausal women. N Engl J Med.
45 Chow CC, Chan WB, Li JK, et al. (2003). Oral alendronate increases bone mineral density in postmenopausal women with primary hyperparathyroidism. J Clin Endocrinol Metab.
46 Ciuffetti G, Ciacca A, Lombardini R, et al. (1991). [Rheologic effects of salmon calcitonin on post-menopausal osteoporosis. Results of a preliminary study]. Minerva medica.
47 Clemmesen B, Ravn P, Zegels B, et al. (1997). A 2-year phase II study with 1-year of follow-up of risedronate (NE-58095) in postmenopausal osteoporosis. Osteoporos Int.
48 Cohen S, Levy RM, Keller M, et al. (1999). Risedronate therapy prevents corticosteroid-induced bone loss: a twelve-month, multicenter, randomized, double-blind, placebo-controlled, parallel-group study. Arthritis Rheum.
49 Combe B, Cohen C, Aubin F. (1997). Equivalence of nasal spray and subcutaneous formulations of salmon calcitonin. Calcified tissue international.
50 Cooper C, Emkey RD, McDonald RH, et al. (2003). Efficacy and safety of oral weekly ibandronate in the treatment of postmenopausal osteoporosis. J Clin Endocrinol Metab.
51 Cortet B, Hachulla E, Barton I, et al. (1999). Evaluation of the efficacy of etidronate therapy in preventing glucocorticoid-induced bone loss in patients with inflammatory rheumatic diseases. A randomized study. Rev Rhum Engl Ed.
52 Cortet B, Bera-Louville A, Gauthier P, et al. (2001). Comparative efficacy and safety study of etidronate and alendronate in postmenopausal osteoporosis. effect of adding hormone replacement therapy. Joint Bone Spine.
53 Cosman F, Nieves J, Woelfert L, et al. (2001). Parathyroid hormone added to established hormone therapy: effects on vertebral fracture and maintenance of bone mass after parathyroid hormone withdrawal. J Bone Miner Res.
54 Cosman F, Nieves J, Zion M, et al. (2005). Daily and cyclic parathyroid hormone in women receiving alendronate. N Engl J Med.
55 Crawford BA, Kam C, Pavlovic J, et al. (2006). Zoledronic acid prevents bone loss after liver transplantation: a randomized, double-blind, placebo-controlled trial. Ann Intern Med.
56 Cryer B, Miller P, Petruschke RA, et al. (2005). Upper gastrointestinal tolerability of once weekly alendronate 70 mg with concomitant non-steroidal anti-inflammatory drug use. Aliment Pharmacol Ther.
57 Cryer B, Binkley N, Simonelli C, et al. (2005). A randomized, placebo-controlled, 6-month study of once-weekly alendronate oral solution for postmenopausal osteoporosis. Am J Geriatr Pharmacother.
58 Cummings SR, Black DM, Thompson DE, et al. (1998). Effect of alendronate on risk of fracture in women with low bone density but without vertebral fractures: results from the Fracture Intervention Trial. JAMA.
59 Cummings SR, Schwartz AV, Black DM. (2007). Alendronate and atrial fibrillation. N Engl J Med.
60 Curb JD, Prentice RL, Bray PF, et al. (2006). Venous thrombosis and conjugated equine estrogen in women without a uterus. Arch Intern Med.
61 Curtis JR, Westfall AO, Allison JJ, et al. Channeling and adherence with alendronate and risedronate among chronic glucocorticoid users. Osteoporos Int 2006.
62 Cushman M, Kuller LH, Prentice R, et al. (2004). Estrogen plus progestin and risk of venous thrombosis. JAMA.
63 D'Amelio P, Muratore M, Tinelli F, et al. (2003). Effect of raloxifene and clodronate on bone density in postmenopausal osteoporotic women. International journal of tissue reactions.
64 Deal C, Omizo M, Schwartz EN, et al. (2005). Combination teriparatide and raloxifene therapy for postmenopausal osteoporosis: results from a 6-month double-blind placebo-controlled trial. J Bone Miner Res.
65 Decensi A, Robertson C, Viale G, et al. (2003). A randomized trial of low-dose tamoxifen on breast cancer proliferation and blood estrogenic biomarkers. Journal of the National Cancer Institute.
66 Delmas PD, Bjarnason NH, Mitlak BH, et al. (1997). Effects of raloxifene on bone mineral density, serum cholesterol concentrations, and uterine endometrium in postmenopausal women. N Engl J Med.
67 Delmas PD, Balena R, Confravreux E, et al. (1997). Bisphosphonate risedronate prevents bone loss in women with artificial menopause due to chemotherapy of breast cancer: a double-blind, placebo-controlled study. J Clin Oncol.
68 Devogelaer JP, Broll H, Correa-Rotter R, et al. (1996). Oral alendronate induces progressive increases in bone mass of the spine, hip, and total body over 3 years in postmenopausal women with osteoporosis. Bone.
69 Doran PM, Riggs BL, Atkinson EJ, et al. (2001). Effects of raloxifene, a selective estrogen receptor modulator, on bone turnover markers and serum sex steroid and lipid levels in elderly men. J Bone Miner Res.
70 Downs RW, Bone HG, McIlwain H, et al. (1999). An open-label extension study of alendronate treatment in elderly women with osteoporosis. Calcif Tissue Int.
71 Downs RW, Bell NH, Ettinger MP, et al. (2000). Comparison of alendronate and intranasal calcitonin for treatment of osteoporosis in postmenopausal women. J Clin Endocrinol Metab.
72 Draper MW, Flowers DE, Huster WJ, et al. (1996). A controlled trial of raloxifene (LY139481) HCl: impact on bone turnover and serum lipid profile in healthy postmenopausal women. J Bone Miner Res.
73 Eastell R, Devogelaer JP, Peel NF, et al. (2000). Prevention of bone loss with risedronate in glucocorticoid-treated rheumatoid arthritis patients. Osteoporos Int.
74 Eisman JA, Rizzoli R, Roman-Ivorra J, et al. (2004). Upper gastrointestinal and overall tolerability of alendronate once weekly in patients with osteoporosis: results of a randomized, double-blind, placebo-controlled study. Curr Med Res Opin.
75 El-Agroudy AE, El-Husseini AA, El-Sayed M, et al. (2005). A prospective randomized study for prevention of postrenal transplantation bone loss. Kidney Int.
76 Ensrud K, Genazzani AR, Geiger MJ, et al. (2006). Effect of raloxifene on cardiovascular adverse events in postmenopausal women with osteoporosis. Am J Cardiol.
77 Ensrud KE, Barrett-Connor EL, Schwartz A, et al. (2004). Randomized trial of effect of alendronate continuation versus discontinuation in women with low BMD: results from the Fracture Intervention Trial long-term extension. J Bone Miner Res.
78 Evans RA, Somers NM, Dunstan CR, et al. (1993). The effect of low-dose cyclical etidronate and calcium on bone mass in early postmenopausal women. Osteoporos Int.
79 Evio S, Tiitinen A, Laitinen K, et al. (2004). Effects of alendronate and hormone replacement therapy, alone and in combination, on bone mass and markers of bone turnover in elderly women with osteoporosis. J Clin Endocrinol Metab.
80 Fan SL, Kumar S, Cunningham J. (2003). Long-term effects on bone mineral density of pamidronate given at the time of renal transplantation. Kidney international.
81 Finkelstein JS, Klibanski A, Arnold AL, et al. (1998). Prevention of estrogen deficiency-related bone loss with human parathyroid hormone-(1–34): a randomized controlled trial. JAMA.
82 Finkelstein JS, Leder BZ, Burnett SA, et al. (2006). Effects of teriparatide, alendronate, or both on bone turnover in osteoporotic men. J Clin Endocrinol Metab.
83 Fisher B, Costantino JP, Wickerham DL, et al. (1998). Tamoxifen for prevention of breast cancer: report of the National Surgical Adjuvant Breast and Bowel Project P-1 Study. J Natl Cancer Inst.
84 Flicker L, Hopper JL, Larkins RG, et al. (1997). Nandrolone decanoate and intranasal calcitonin as therapy in established osteoporosis. Osteoporosis international : a journal established as result of cooperation between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
85 Fogelman I, Herd RJ, Blake GM, et al. (2000). Cyclical etidronate therapy for prevention of postmenopausal bone loss: a 1-year open-label follow-up study. Calcif Tissue Int.
86 Fogelman I, Ribot C, Smith R, et al. (2000). Risedronate reverses bone loss in postmenopausal women with low bone mass: results from a multinational, double-blind, placebo-controlled trial. BMD-MN Study Group. J Clin Endocrinol Metab.
87 Frediani B, Allegri A, Bisogno S, et al. (1998). Effects of combined treatment with calcitriol plus alendronate on bone mass and bone turnover in postmenopausal osteoporosis: Two years of continuous treatment. Clinical Drug Investigation.
88 Freedman M, San Martin J, O'Gorman J, et al. (2001). Digitized mammography: a clinical trial of postmenopausal women randomly assigned to receive raloxifene, estrogen, or placebo. J Natl Cancer Inst.
89 Fujita T, Inoue T, Morii H, et al. (1999). Effect of an intermittent weekly dose of human parathyroid hormone (1–34) on osteoporosis: a randomized double-masked prospective study using three dose levels. Osteoporosis international : a journal established as result of cooperation between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
90 Fukunaga M, Kushida K, Kishimoto H, et al. (2002). A comparison of the effect of risedronate and etidronate on lumbar bone mineral density in Japanese patients with osteoporosis: a randomized controlled trial. Osteoporos Int.
91 Fuleihan Gel-H, Salamoun M, Mourad YA, et al. (2005). Pamidronate in the prevention of chemotherapy-induced bone loss in premenopausal women with breast cancer: a randomized controlled trial. J Clin Endocrinol Metab.
92 Geusens P, Vanhoof JSR, Joly J, et al. (1997). Cyclic etidronate increases bone density in the spine and hip in postmenopausal women on chronic corticosteroid treatment. A double-blind controlled study. Bone.
93 Geusens P, Dequeker J, Vanhoof J, et al. (1998). Cyclical etidronate increases bone density in the spine and hip of postmenopausal women receiving long term corticosteroid treatment. A double blind, randomised placebo controlled study. Ann Rheum Dis.
94 Giannini S, D'Angelo A, Carraro G, et al. (2001). Alendronate prevents further bone loss in renal transplant recipients. Journal of bone and mineral research : the official journal of the American Society for Bone and Mineral Research.
95 Gnudi S, Mongiorgi R, Moroni A, et al. (1988). Densitometric analysis in in vivo evaluation of synthetic salmon calcitonin activity. J Clin Pharm Ther.
96 Golden NH, Iglesias EA, Jacobson MS, et al. (2005). Alendronate for the treatment of osteopenia in anorexia nervosa: a randomized, double-blind, placebo-controlled trial. J Clin Endocrinol Metab.
97 Grady D, Ettinger B, Moscarelli E, et al. (2004). Safety and adverse effects associated with raloxifene: multiple outcomes of raloxifene evaluation. Obstet Gynecol.
98 Greenspan S, Field-Munves E, Tonino R, et al. (2002). Tolerability of once-weekly alendronate in patients with osteoporosis: a randomized, double-blind, placebo-controlled study. Mayo Clin Proc.
99 Greenspan SL, Parker RA, Ferguson L, et al. (1998). Early changes in biochemical markers of bone turnover predict the long-term response to alendronate therapy in representative elderly women: a randomized clinical trial. J Bone Miner Res.
100 Greenspan SL, Resnick NM, Parker RA. (2003). Combination therapy with hormone replacement and alendronate for prevention of bone loss in elderly women: a randomized controlled trial. JAMA.
101 Greenwald MW, Gluck OS, Lang E, et al. (2005). Oral hormone therapy with 17beta-estradiol and 17beta-estradiol in combination with norethindrone acetate in the prevention of bone loss in early postmenopausal women: dose-dependent effects. Menopause.
102 Grey AB, Stapleton JP, Evans MC, et al. (1995). The effect of the antiestrogen tamoxifen on bone mineral density in normal late postmenopausal women. Am J Med.
103 Grotz W, Nagel C, Poeschel D, et al. (2001). Effect of ibandronate on bone loss and renal function after kidney transplantation. Journal of the American Society of Nephrology : JASN.
104 Grotz WH, Rump LC, Niessen A, et al. (1998). Treatment of osteopenia and osteoporosis after kidney transplantation. Transplantation.
105 Gruber HE, Ivey JL, Baylink DJ, et al. (1984). Long-term calcitonin therapy in postmenopausal osteoporosis. Metabolism.
106 Guanabens N, Farrerons J, Perez-Edo L, et al. (2000). Cyclical etidronate versus sodium fluoride in established postmenopausal osteoporosis: a randomized 3 year trial. Bone.
107 Guanabens N PARIALPFCLMAMdOMRMPPRJ. Alendronate is more effective than etidronate for increasing bone mass in osteopenic patients with primary biliary cirrhosis. The American journal of gastroenterology 2003;98(10):2268–74.
108 Guaraldi G, Orlando G, Madeddu G, et al. (2004). Alendronate reduces bone resorption in HIV-associated osteopenia/osteoporosis. HIV clinical trials.
109 Gurlek A, Bayraktar M, Gedik O. (1997). Comparison of calcitriol treatment with etidronate-calcitriol and calcitonin-calcitriol combinations in Turkish women with postmenopausal osteoporosis: a prospective study. Calcif Tissue Int.
110 Gutteridge DH, Stewart GO, Prince RL, et al. (2002). A randomized trial of sodium fluoride (60 mg) +/- estrogen in postmenopausal osteoporotic vertebral fractures: increased vertebral fractures and peripheral bone loss with sodium fluoride; concurrent estrogen prevents peripheral loss, but not vertebral fractures. Osteoporos Int.
111 Haderslev KV, Tjellesen L, Sorensen HA, et al. (2000). Alendronate increases lumbar spine bone mineral density in patients with Crohn's disease. Gastroenterology.
112 Harris ST, Gertz BJ, Genant HK, et al. (1993). The effect of short term treatment with alendronate on vertebral density and biochemical markers of bone remodeling in early postmenopausal women. J Clin Endocrinol Metab.
113 Harris ST, Watts NB, Genant HK, et al. (1999). Effects of risedronate treatment on vertebral and nonvertebral fractures in women with postmenopausal osteoporosis: a randomized controlled trial. Vertebral Efficacy With Risedronate Therapy (VERT) Study Group. JAMA.
114 Harris ST, Eriksen EF, Davidson M, et al. (2001). Effect of combined risedronate and hormone replacement therapies on bone mineral density in postmenopausal women. J Clin Endocrinol Metab.
115 Harris ST, Watts NB, Li Z, et al. (2004). Two-year efficacy and tolerability of risedronate once a week for the treatment of women with postmenopausal osteoporosis. Curr Med Res Opin.
116 Hasling C, Charles P, Jensen FT, et al. (1994). A comparison of the effects of oestrogen/progestogen, high-dose oral calcium, intermittent cyclic etidronate and an ADFR regime on calcium kinetics and bone mass in postmenopausal women with spinal osteoporosis. Osteoporos Int.
117 Haworth CS SPAJMEHAWA. Effect of intravenous pamidronate on bone mineral density in adults with cystic fibrosis. Thorax 2001;56(4):314–6.
118 Hay JE, Malinchoc M, Dickson ER. (2001). A controlled trial of calcitonin therapy for the prevention of post-liver transplantation atraumatic fractures in patients with primary biliary cirrhosis and primary sclerosing cholangitis. J Hepatol.
119 Heath DA, Bullivant BG, Boiven C, et al. (2000). The effects of cyclical etidronate on early postmenopausal bone loss: an open, randomized controlled study. J Clin Densitom.
120 Henderson S, Hoffman N, Prince R. (2006). A double-blind placebo-controlled study of the effects of the bisphosphonate risedronate on bone mass in patients with inflammatory bowel disease. Am J Gastroenterol.
121 Hendrix SL, Wassertheil-Smoller S, Johnson KC, et al. (2006). Effects of conjugated equine estrogen on stroke in the Women's Health Initiative. Circulation.
122 Herd RJ, Balena R, Blake GM, et al. (1997). The prevention of early postmenopausal bone loss by cyclical etidronate therapy: a 2-year, double-blind, placebo-controlled study. Am J Med.
123 Herrera JA, Sarabia MO, Gonzalez MM. (1999). Effects of treatment with bisphosphonates on gastrointestinal and esophageal mucosa in patients with osteoporosis: Pamidronate versus alendronate. Current Therapeutic Research, Clinical & Experimental.
124 Ho AY, Kung AW. (2005). Efficacy and tolerability of alendronate once weekly in Asian postmenopausal osteoporotic women. Ann Pharmacother.
125 Hooper MJ, Ebeling PR, Roberts AP, et al. (2005). Risedronate prevents bone loss in early postmenopausal women: a prospective randomized, placebo-controlled trial. Climacteric.
126 Horwitz MJ, Tedesco MB, Gundberg C, et al. (2003). Short-term, high-dose parathyroid hormone-related protein as a skeletal anabolic agent for the treatment of postmenopausal osteoporosis. J Clin Endocrinol Metab.
127 Hosking D, Chilvers CE, Christiansen C, et al. (1998). Prevention of bone loss with alendronate in postmenopausal women under 60 years of age. Early Postmenopausal Intervention Cohort Study Group. N Engl J Med.
128 Hosking D, Adami S, Felsenberg D, et al. (2003). Comparison of change in bone resorption and bone mineral density with once-weekly alendronate and daily risedronate: a randomised, placebo-controlled study. Current medical research and opinion.
129 Howell SJ, Radford JA, Adams JE, et al. (2001). Randomized placebo-controlled trial of testosterone replacement in men with mild Leydig cell insufficiency following cytotoxic chemotherapy. Clinical Endocrinology.
130 Hsia J, Criqui MH, Rodabough RJ, et al. (2004). Estrogen plus progestin and the risk of peripheral arterial disease: the Women's Health Initiative. Circulation.
131 Hsia J, Langer RD, Manson JE, et al. (2006). Conjugated equine estrogens and coronary heart disease: the Women's Health Initiative. Arch Intern Med.
132 Hulley S, Grady D, Bush T, et al. (1998). Randomized trial of estrogen plus progestin for secondary prevention of coronary heart disease in postmenopausal women. Heart and Estrogen/progestin Replacement Study (HERS) Research Group. JAMA.
133 Hulley S, Furberg C, Barrett-Connor E, et al. (2002). Noncardiovascular disease outcomes during 6.8 years of hormone therapy: Heart and Estrogen/progestin Replacement Study follow-up (HERS II). JAMA.
134 Huusko TM, Karppi P, Kautiainen H, et al. (2002). Randomized, double-blind, clinically controlled trial of intranasal calcitonin treatment in patients with hip fracture. Calcif Tissue Int.
135 Hwang JS, Tu ST, Yang TS, et al. (2006). Teriparatide vs. calcitonin in the treatment of Asian postmenopausal women with established osteoporosis. Osteoporos Int.
136 Ilter E, Karalok H, Tufekci EC, et al. (2006). Efficacy and acceptability of risedronate 5 mg daily compared with 35 mg once weekly for the treatment of postmenopausal osteoporosis. Climacteric.
137 Ishida Y, Kawai S. (2004). Comparative efficacy of hormone replacement therapy, etidronate, calcitonin, alfacalcidol, and vitamin K in postmenopausal women with osteoporosis: The Yamaguchi Osteoporosis Prevention Study. The American Journal of Medicine.
138 Iwamoto J TTIS. Effect of menatetrenone on bone mineral density and incidence of vertebral fractures in postmenopausal women with osteoporosis: a comparison with the effect of etidronate. Journal of orthopaedic science : official journal of the Japanese Orthopaedic Association 2001;6(6):487–92.
139 Iwamoto J, Takeda T, Sato Y, et al. (2005). Comparison of effect of treatment with etidronate and alendronate on lumbar bone mineral density in elderly women with osteoporosis. Yonsei Med J.
140 Jeffery JR LWKMNPRD. Prevalence and treatment of decreased bone density in renal transplant recipients: a randomized prospective trial of calcitriol versus alendronate. Transplantation 2003;76(10):1498–502.
141 Jeffrey J, Leslie W, Karpinski M, et al. (2003). Prevalence and treatment of decreased bone density in renal transplant recipients: a randomized prospective trial of calcitriol versus alendronate. Transplantation.
142 Jodar E, Munoz-Torres M, Escobar-Jimenez F, et al. (1997). Antiresorptive therapy in hyperthyroid patients: longitudinal changes in bone and mineral metabolism. The Journal of clinical endocrinology and metabolism.
143 Johnell O, Scheele WH, Lu Y, et al. (2002). Additive effects of raloxifene and alendronate on bone density and biochemical markers of bone remodeling in postmenopausal women with osteoporosis. J Clin Endocrinol Metab.
144 Johnell O, Cauley JA, Kulkarni PM, et al. (2004). Raloxifene reduces risk of vertebral fractures. J Fam Pract.
145 Johnston CC, Bjarnason NH, Cohen FJ, et al. (2000). Long-term effects of raloxifene on bone mineral density, bone turnover, and serum lipid levels in early postmenopausal women: three-year data from 2 double-blind, randomized, placebo-controlled trials. Arch Intern Med.
146 Jolly EE, Bjarnason NH, Neven P, et al. (2003). Prevention of osteoporosis and uterine effects in postmenopausal women taking raloxifene for 5 years. Menopause.
147 Kananen K, Volin L, Laitinen K, et al. (2005). Prevention of bone loss after allogeneic stem cell transplantation by calcium, vitamin D, and sex hormone replacement with or without pamidronate. J Clin Endocrinol Metab.
148 Kaufman JM, Orwoll E, Goemaere S, et al. (2005). Teriparatide effects on vertebral fractures and bone mineral density in men with osteoporosis: treatment and discontinuation of therapy. Osteoporos Int.
149 Keegan TH, Schwartz AV, Bauer DC, et al. (2004). Effect of alendronate on bone mineral density and biochemical markers of bone turnover in type 2 diabetic women: the fracture intervention trial. Diabetes Care.
150 Kendler D KAFG-HGGJGKVNMM. Patients with osteoporosis prefer once weekly to once daily dosing with alendronate. Maturitas 2004;48(3):243–51.
151 Kenny AM, Prestwood KM, Gruman CA, et al. (2001). Effects of transdermal testosterone on bone and muscle in older men with low bioavailable testosterone levels. The journals of gerontology Series A, Biological sciences and medical sciences.
152 Kim SH, Lim SK, Hahn JS. (2004). Effect of pamidronate on new vertebral fractures and bone mineral density in patients with malignant lymphoma receiving chemotherapy. The American journal of medicine.
153 Kishimoto H, Fukunaga M, Kushida K, et al. (2006). Efficacy and tolerability of once-weekly administration of 17.5 mg risedronate in Japanese patients with involutional osteoporosis: a comparison with 2.5-mg once-daily dosage regimen. J Bone Miner Metab.
154 Kotaniemi A, Piirainen H, Paimela L, et al. (1996). Is continuous intranasal salmon calcitonin effective in treating axial bone loss in patients with active rheumatoid arthritis receiving low dose glucocorticoid therapy?. J Rheumatol.
155 Kristensen B, Ejlertsen B, Dalgaard P, et al. (1994). Tamoxifen and bone metabolism in postmenopausal low-risk breast cancer patients: a randomized study. Journal of clinical oncology : official journal of the American Society of Clinical Oncology.
156 Kung AW, Yeung SS, Chu LW. (2000). The efficacy and tolerability of alendronate in postmenopausal osteoporotic Chinese women: a randomized placebo-controlled study. Calcif Tissue Int.
157 Kung AW, Chao HT, Huang KE, et al. (2003). Efficacy and safety of raloxifene 60 milligrams/day in postmenopausal Asian women. J Clin Endocrinol Metab.
158 Kung AW, Pasion EG, Sofiyan M, et al. (2006). A comparison of teriparatide and calcitonin therapy in postmenopausal Asian women with osteoporosis: a 6-month study. Curr Med Res Opin.
159 Kurland ES, Cosman F, McMahon DJ, et al. (2000). Parathyroid hormone as a therapy for idiopathic osteoporosis in men: effects on bone mineral density and bone markers. J Clin Endocrinol Metab.
160 Kushida K, Fukunaga M, Kishimoto H, et al. (2002). The efficacy of alendronate in reducing the risk for vertebral fracture in Japanese patients with osteoporosis: A randomized, double-blind, active-controlled, double-dummy trial. Current Therapeutic Research, Clinical & Experimental.
161 Kushida K, Fukunaga M, Kishimoto H, et al. (2004). A comparison of incidences of vertebral fracture in Japanese patients with involutional osteoporosis treated with risedronate and etidronate: a randomized, double-masked trial. Journal of Bone and Mineral Metabolism.
162 Kushida K, Shiraki M, Nakamura T, et al. (2004). Alendronate reduced vertebral fracture risk in postmenopausal Japanese women with osteoporosis: a 3-year follow-up study. Journal of bone and mineral metabolism.
163 Lane NE, Sanchez S, Modin GW, et al. (1998). Parathyroid hormone treatment can reverse corticosteroid-induced osteoporosis. Results of a randomized controlled clinical trial. J Clin Invest.
164 Lau EM, Woo J, Chan YH, et al. (2000). Alendronate prevents bone loss in Chinese women with osteoporosis. Bone.
165 Lau EM, Woo J, Chan YH, et al. (2001). Alendronate for the prevention of bone loss in patients on inhaled steroid therapy. Bone.
166 Layton D, Clarke A, Wilton LV, et al. (2005). Safety profile of raloxifene as used in general practice in England: results of a prescription-event monitoring study. Osteoporos Int.
167 Lees B, Garland SW, Walton C, et al. (1996). Role of oral pamidronate in preventing bone loss in postmenopausal women. Osteoporosis international : a journal established as result of cooperation between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
168 Lindsay R, Nieves J, Formica C, et al. (1997). Randomised controlled study of effect of parathyroid hormone on vertebral-bone mass and fracture incidence among postmenopausal women on oestrogen with osteoporosis. Lancet.
169 Lindsay R, Cosman F, Lobo RA, et al. (1999). Addition of alendronate to ongoing hormone replacement therapy in the treatment of osteoporosis: a randomized, controlled clinical trial. The Journal of clinical endocrinology and metabolism.
170 Lindsay R, Gallagher JC, Kleerekoper M, et al. (2002). Effect of lower doses of conjugated equine estrogens with and without medroxyprogesterone acetate on bone in early postmenopausal women. JAMA.
171 Liu JL, Zhu HM, Huang QR, et al. (2004). Effects of raloxifene hydrochloride on bone mineral density, bone metabolism and serum lipids in Chinese postmenopausal women with osteoporosis: a multi-center, randomized, placebo-controlled clinical trial. Chin Med J (Engl).
172 Love RR, Mazess RB, Barden HS, et al. (1992). Effects of tamoxifen on bone mineral density in postmenopausal women with breast cancer. N Engl J Med.
173 Luckey M, Kagan R, Greenspan S, et al. (2004). Once-weekly alendronate 70 mg and raloxifene 60 mg daily in the treatment of postmenopausal osteoporosis. Menopause.
174 Luckey MM, Gilchrist N, Bone HG, et al. (2003). Therapeutic equivalence of alendronate 35 milligrams once weekly and 5 milligrams daily in the prevention of postmenopausal osteoporosis. Obstet Gynecol.
175 Luengo M, Pons F, Martinez de Osaba MJ, et al. (1994). Prevention of further bone mass loss by nasal calcitonin in patients on long term glucocorticoid therapy for asthma: a two year follow up study. Thorax.
176 Lufkin EG, Wahner HW, O'Fallon WM, et al. (1992). Treatment of postmenopausal osteoporosis with transdermal estrogen. Ann Intern Med.
177 Lufkin EG ARWMCAWVEKOWRB. Pamidronate: an unrecognized problem in gastrointestinal tolerability. Osteoporosis international : a journal established as result of cooperation between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA 1994;4(6):320–2.
178 Lyritis GP, Paspati I, Karachalios T, et al. (1997). Pain relief from nasal salmon calcitonin in osteoporotic vertebral crush fractures. A double blind, placebo-controlled clinical study. Acta Orthop Scand Suppl.
179 Lyritis GP, Ioannidis GV, Karachalios T, et al. (1999). Analgesic effect of salmon calcitonin suppositories in patients with acute pain due to recent osteoporotic vertebral crush fractures: a prospective double-blind, randomized, placebo-controlled clinical study. The Clinical journal of pain.
180 Mackay FJ, Wilton LV, Pearce GL, et al. (1998). United Kingdom experience with alendronate and oesophageal reactions. Br J Gen Pract.
181 Manson JE, Hsia J, Johnson KC, et al. (2003). Estrogen plus progestin and the risk of coronary heart disease. N Engl J Med.
182 Masud T, Mulcahy B, Thompson AV, et al. (1998). Effects of cyclical etidronate combined with calcitriol versus cyclical etidronate alone on spine and femoral neck bone mineral density in postmenopausal osteoporotic women. Ann Rheum Dis.
183 McClung M, Clemmesen B, Daifotis A, et al. (1998). Alendronate prevents postmenopausal bone loss in women without osteoporosis. A double-blind, randomized, controlled trial. Alendronate Osteoporosis Prevention Study Group. Annals of internal medicine.
184 McClung MR, Geusens P, Miller PD, et al. (2001). Effect of risedronate on the risk of hip fracture in elderly women. Hip Intervention Program Study Group. N Engl J Med.
185 McClung MR, Wasnich RD, Recker R, et al. (2004). Oral daily ibandronate prevents bone loss in early postmenopausal women without osteoporosis. J Bone Miner Res.
186 McClung MR, Wasnich RD, Hosking DJ, et al. (2004). Prevention of postmenopausal bone loss: six-year results from the Early Postmenopausal Intervention Cohort Study. J Clin Endocrinol Metab.
187 McClung MR, San Martin J, Miller PD, et al. (2005). Opposite bone remodeling effects of teriparatide and alendronate in increasing bone mass. Arch Intern Med.
188 McClung MR, Lewiecki EM, Cohen SB, et al. (2006). Denosumab in postmenopausal women with low bone mineral density. N Engl J Med.
189 Mellstrom DD, Sorensen OH, Goemaere S, et al. (2004). Seven years of treatment with risedronate in women with postmenopausal osteoporosis. Calcif Tissue Int.
190 Merza Z, Blumsohn A, Mah PM, et al. (2006). Double-blind placebo-controlled study of testosterone patch therapy on bone turnover in men with borderline hypogonadism. Int J Androl.
191 Meunier PJ, Confavreux E, Tupinon I, et al. (1997). Prevention of early postmenopausal bone loss with cyclical etidronate therapy (a double-blind, placebo-controlled study and 1-year follow-up). J Clin Endocrinol Metab.
192 Meunier PJ, Vignot E, Garnero P, et al. (1999). Treatment of postmenopausal women with osteoporosis or low bone density with raloxifene. Raloxifene Study Group. Osteoporos Int.
193 Michalska D, Stepan JJ, Basson BR, et al. (2006). The effect of raloxifene after discontinuation of long-term alendronate treatment of postmenopausal osteoporosis. J Clin Endocrinol Metab.
194 Milgrom C, Finestone A, Novack V, et al. (2004). The effect of prophylactic treatment with risedronate on stress fracture incidence among infantry recruits. Bone.
195 Miller PD, Watts NB, Licata AA, et al. (1997). Cyclical etidronate in the treatment of postmenopausal osteoporosis: efficacy and safety after seven years of treatment. Am J Med.
196 Miller PD, Woodson G, Licata AA, et al. (2000). Rechallenge of patients who had discontinued alendronate therapy because of upper gastrointestinal symptoms. Clinical therapeutics.
197 Miller PD, Schwartz EN, Chen P, et al. Teriparatide in postmenopausal women with osteoporosis and mild or moderate renal impairment. Osteoporos Int 2006.
198 Miller RG. (1969). The treatment of osteoporosis. A report of a double blind clinical therapeutic trial. Gerontol Clin (Basel).
199 Morabito N, Lasco A, Gaudio A, et al. (2002). Bisphosphonates in the treatment of thalassemia-induced osteoporosis. Osteoporos Int.
200 Morabito N, Gaudio A, Lasco A, et al. (2003). Three-year effectiveness of intravenous pamidronate versus pamidronate plus slow-release sodium fluoride for postmenopausal osteoporosis. Osteoporos Int.
201 Moran de Brito CM, Battistella LR, Saito ET, et al. (2005). Effect of alendronate on bone mineral density in spinal cord injury patients: a pilot study. Spinal Cord.
202 Morii H, Ohashi Y, Taketani Y, et al. (2003). Effect of raloxifene on bone mineral density and biochemical markers of bone turnover in Japanese postmenopausal women with osteoporosis: results from a randomized placebo-controlled trial. Osteoporos Int.
203 Mortensen L, Charles P, Bekker PJ, et al. (1998). Risedronate increases bone mass in an early postmenopausal population: two years of treatment plus one year of follow-up. J Clin Endocrinol Metab.
204 Mosekilde L, Beck-Nielsen H, Sorensen OH, et al. (2000). Hormonal replacement therapy reduces forearm fracture incidence in recent postmenopausal women - results of the Danish Osteoporosis Prevention Study. Maturitas.
205 Murphy MG, Weiss S, McClung M, et al. (2001). Effect of alendronate and MK-677 (a growth hormone secretagogue), individually and in combination, on markers of bone turnover and bone mineral density in postmenopausal osteoporotic women. The Journal of clinical endocrinology and metabolism.
206 Nakayamada S, Okada Y, Saito K, et al. (2004). Etidronate prevents high dose glucocorticoid induced bone loss in premenopausal individuals with systemic autoimmune diseases. The Journal of Rheumatology.
207 Neer RM, Arnaud CD, Zanchetta JR, et al. (2001). Effect of parathyroid hormone (1–34) on fractures and bone mineral density in postmenopausal women with osteoporosis. N Engl J Med.
208 Neven P, Lunde T, Benedetti-Panici P, et al. (2003). A multicentre randomised trial to compare uterine safety of raloxifene with a continuous combined hormone replacement therapy containing oestradiol and norethisterone acetate. BJOG.
209 Neven P QDLMAFTHDGCGMBHB-LBSHHANT. Uterine effects of estrogen plus progestin therapy and raloxifene: adjudicated results from the EURALOX study. Obstetrics and gynecology 2004;103(5 Pt 1):881–91.
210 Nickelsen T, Lufkin EG, Riggs BL, et al. (1999). Raloxifene hydrochloride, a selective estrogen receptor modulator: safety assessment of effects on cognitive function and mood in postmenopausal women. Psychoneuroendocrinology.
211 Ninkovic M, Love S, Tom BD, et al. (2002). Lack of effect of intravenous pamidronate on fracture incidence and bone mineral density after orthotopic liver transplantation. J Hepatol.
212 Notelovitz M, John VA, Good WR. (2002). Effectiveness of Alora estradiol matrix transdermal delivery system in improving lumbar bone mineral density in healthy, postmenopausal women. Menopause.
213 Orwoll E, Ettinger M, Weiss S, et al. (2000). Alendronate for the treatment of osteoporosis in men. N Engl J Med.
214 Orwoll ES, Scheele WH, Paul S. (2003). The effects of teriparatide[human parathyroid hormone(1–34)] therapy on bone density in men with osteoporosis. J Bone Miner Res.
215 Palomba S, Orio F, Colao A, et al. (2002). Effect of estrogen replacement plus low-dose alendronate treatment on bone density in surgically postmenopausal women with osteoporosis. J Clin Endocrinol Metab.
216 Palomba S, Orio F, Manguso F, et al. (2005). Efficacy of risedronate administration in osteoporotic postmenopausal women affected by inflammatory bowel disease. Osteoporos Int.
217 Peichl P RBKWBH. Increase of axial and appendicular trabecular and cortical bone density in established osteoporosis with intermittent nasal salmon calcitonin therapy. Gynecological endocrinology : the official journal of the International Society of Gynecological Endocrinology 1999;13(1):7–14.
218 Peichl P, Marteau R, Griesmacher A, et al. (2005). Salmon calcitonin nasal spray treatment for postmenopausal women after hip fracture with total hip arthroplasty. J Bone Miner Metab.
219 Pereda CA HRNKER. The impact of subcutaneous oestradiol implants on biochemical markers of bone turnover and bone mineral density in postmenopausal women. BJOG : an international journal of obstetrics and gynaecology 2002;109(7):812–20.
220 Pitt P, Li F, Bloom B, et al. (1997). A double-blind placebo controlled study to determine the effects of intermittent cyclical etidronate on bone mineral density in patients on long term corticosteroid treatment. Bone.
221 Pitt P, Li F, Todd P, et al. (1998). A double blind placebo controlled study to determine the effects of intermittent cyclical etidronate on bone mineral density in patients on long-term oral corticosteroid treatment. Thorax.
222 Pols HA, Felsenberg D, Hanley DA, et al. (1999). Multinational, placebo-controlled, randomized trial of the effects of alendronate on bone density and fracture risk in postmenopausal women with low bone mass: results of the FOSIT study. Foxamax International Trial Study Group. Osteoporos Int.
223 Pouilles JM, Tremollieres F, Roux C, et al. (1997). Effects of cyclical etidronate therapy on bone loss in early postmenopausal women who are not undergoing hormonal replacement therapy. Osteoporosis international : a journal established as result of cooperation between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
224 Ravn P, Clemmesen B, Riis BJ, et al. (1996). The effect on bone mass and bone markers of different doses of ibandronate: a new bisphosphonate for prevention and treatment of postmenopausal osteoporosis: a 1-year, randomized, double-blind, placebo-controlled dose-finding study. Bone.
225 Ravn P, Weiss SR, Rodriguez-Portales JA, et al. (2000). Alendronate in early postmenopausal women: effects on bone mass during long-term treatment and after withdrawal. Alendronate Osteoporosis Prevention Study Group. The Journal of clinical endocrinology and metabolism.
226 Recker R, Stakkestad JA, Chesnut CH, et al. (2004). Insufficiently dosed intravenous ibandronate injections are associated with suboptimal antifracture efficacy in postmenopausal osteoporosis. Bone.
227 Recker R, Lips P, Felsenberg D, et al. (2006). Alendronate with and without cholecalciferol for osteoporosis: results of a 15-week randomized controlled trial. Curr Med Res Opin.
228 Recker RR, Davies KM, Dowd RM, et al. (1999). The effect of low-dose continuous estrogen and progesterone therapy with calcium and vitamin D on bone in elderly women. A randomized, controlled trial. Ann Intern Med.
229 Recker RR, Kendler D, Recknor CP, et al. Comparative effects of raloxifene and alendronate on fracture outcomes in postmenopausal women with low bone mass. Bone 2006.
230 Reginster J, Minne H, Sorensen OH. (2000). Randomized trial of the effects of risedronate on vetebral fractures in women with established postmenopausal osteoporosis. Osteoposos Int.
231 Reginster JY, Denis D, Albert A, et al. (1987). 1-Year controlled randomised trial of prevention of early postmenopausal bone loss by intranasal calcitonin. Lancet.
232 Reginster JY, Deroisy R, Lecart MP, et al. (1995). A double-blind, placebo-controlled, dose-finding trial of intermittent nasal salmon calcitonin for prevention of postmenopausal lumbar spine bone loss. Am J Med.
233 Reginster JY, Felsenberg D, Pavo I, et al. (2003). Effect of raloxifene combined with monofluorophosphate as compared with monofluorophosphate alone in postmenopausal women with low bone mass: a randomized, controlled trial. Osteoporos Int.
234 Reginster JY, Wilson KM, Dumont E, et al. (2005). Monthly oral ibandronate is well tolerated and efficacious in postmenopausal women: results from the monthly oral pilot study. J Clin Endocrinol Metab.
235 Reginster JY, Adami S, Lakatos P, et al. (2006). Efficacy and tolerability of once-monthly oral ibandronate in postmenopausal osteoporosis: 2 year results from the MOBILE study. Ann Rheum Dis.
236 Reid DM, Hughes RA, Laan RF, et al. (2000). Efficacy and safety of daily risedronate in the treatment of corticosteroid-induced osteoporosis in men and women: a randomized trial. European Corticosteroid-Induced Osteoporosis Treatment Study. J Bone Miner Res.
237 Reid IR, King AR, Alexander CJ, et al. (1988). Prevention of steroid-induced osteoporosis with (3-amino-1-hydroxypropylidene)-1,1-bisphosphonate (APD). Lancet.
238 Reid IR, Wattie DJ, Evans MC, et al. (1994). Continuous therapy with pamidronate, a potent bisphosphonate, in postmenopausal osteoporosis. J Clin Endocrinol Metab.
239 Reid IR, Brown JP, Burckhardt P, et al. (2002). Intravenous zoledronic acid in postmenopausal women with low bone mineral density. N Engl J Med.
240 Reid IR, Eastell R, Fogelman I, et al. (2004). A comparison of the effects of raloxifene and conjugated equine estrogen on bone and lipids in healthy postmenopausal women. Arch Intern Med.
241 Rhee Y, Kang M, Min Y, et al. (2006). Effects of a combined alendronate and calcitriol agent (Maxmarvil(R)) on bone metabolism in Korean postmenopausal women: a multicenter, double-blind, randomized, placebo-controlled study. Osteoporos Int.
242 Riis BJ, Ise J, von Stein T, et al. (2001). Ibandronate: a comparison of oral daily dosing versus intermittent dosing in postmenopausal osteoporosis. J Bone Miner Res.
243 Ringe JD, Faber H, Dorst A. (2001). Alendronate treatment of established primary osteoporosis in men: results of a 2-year prospective study. The Journal of clinical endocrinology and metabolism.
244 Ringe JD, Dorst A, Faber H, et al. (2003). Three-monthly ibandronate bolus injection offers favourable tolerability and sustained efficacy advantage over two years in established corticosteroid-induced osteoporosis. Rheumatology (Oxford).
245 Ringe JD, Coser A, Dorst A. Alendronate treatment of established primary osteoporosis in men: two-year results of a prospective comparative two-arm study. Osteoporo Int. in press;(In Press).
246 Ringe JD, Dorst A, Faber H, et al. (2003). Intermittent intravenous ibandronate injections reduce vertebral fracture risk in corticosteroid-induced osteoporosis: results from a long-term comparative study. Osteoporos Int.
247 Ringe JD, Dorst A, Faber H, et al. (2005). Efficacy of etidronate and sequential monofluorophosphate in severe postmenopausal osteoporosis: a pilot study. Rheumatol Int.
248 Ringe JD, Faber H, Farahmand P, et al. (2006). Efficacy of risedronate in men with primary and secondary osteoporosis: results of a 1-year study. Rheumatol Int.
249 Rizzoli R, Greenspan SL, Bone G, et al. (2002). Two-year results of once-weekly administration of alendronate 70 mg for the treatment of postmenopausal osteoporosis. J Bone Miner Res.
250 Rosen CJ, Hochberg MC, Bonnick SL, et al. (2005). Treatment with once-weekly alendronate 70 mg compared with once-weekly risedronate 35 mg in women with postmenopausal osteoporosis: a randomized double-blind study. J Bone Miner Res.
251 Rossini M, Gatti D, Girardello S, et al. (2000). Effects of two intermittent alendronate regimens in the prevention or treatment of postmenopausal osteoporosis. Bone.
252 Rossouw JE, Anderson GL, Prentice RL, et al. (2002). Risks and benefits of estrogen plus progestin in healthy postmenopausal women: principal results From the Women's Health Initiative randomized controlled trial. JAMA.
253 Roux C, Oriente P, Laan R, et al. (1998). Randomized trial of effect of cyclical etidronate in the prevention of corticosteroid-induced bone loss. Ciblos Study Group. J Clin Endocrinol Metab.
254 Rubin MR, Lee KH, McMahon DJ, et al. (2003). Raloxifene lowers serum calcium and markers of bone turnover in postmenopausal women with primary hyperparathyroidism. J Clin Endocrinol Metab.
255 Ryan PJ, Blake GM, Davie M, et al. (2000). Intermittent oral disodium pamidronate in established osteoporosis: a 2 year double-masked placebo-controlled study of efficacy and safety. Osteoporosis international : a journal established as result of cooperation between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
256 Saag KG, Emkey R, Schnitzer TJ, et al. (1998). Alendronate for the prevention and treatment of glucocorticoid-induced osteoporosis. Glucocorticoid-Induced Osteoporosis Intervention Study Group. N Engl J Med.
257 Sahota O, Fowler I, Blackwell PJ, et al. (2000). A comparison of continuous alendronate, cyclical alendronate and cyclical etidronate with calcitriol in the treatment of postmenopausal vertebral osteoporosis: a randomized controlled trial. Osteoporosis international : a journal established as result of cooperation between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
258 Sambrook P, Birmingham J, Kelly P, et al. (1993). Prevention of corticosteroid osteoporosis. A comparison of calcium, calcitriol, and calcitonin. N Engl J Med.
259 Sambrook PN, Kotowicz M, Nash P, et al. (2003). Prevention and treatment of glucocorticoid-induced osteoporosis: a comparison of calcitriol, vitamin D plus calcium, and alendronate plus calcium. J Bone Miner Res.
260 Sambrook PN, Rodriguez JP, Wasnich RD, et al. (2004). Alendronate in the prevention of osteoporosis: 7-year follow-up. Osteoporosis international : a journal established as result of cooperation between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
261 Sambrook PN, Geusens P, Ribot C, et al. (2004). Alendronate produces greater effects than raloxifene on bone density and bone turnover in postmenopausal women with low bone density: results of EFFECT (Efficacy of FOSAMAX versus EVISTA Comparison Trial) International. Journal of internal medicine.
262 Sato S, Ohosone Y, Suwa A, et al. (2003). Effect of intermittent cyclical etidronate therapy on corticosteroid induced osteoporosis in Japanese patients with connective tissue disease: 3 year followup. J Rheumatol.
263 Sato Y, Asoh T, Kaji M, et al. (2000). Beneficial effect of intermittent cyclical etidronate therapy in hemiplegic patients following an acute stroke. Journal of bone and mineral research : the official journal of the American Society for Bone and Mineral Research.
264 Sato Y, Kanoko T, Yasuda H, et al. (2004). Beneficial effect of etidronate therapy in immobilized hip fracture patients. Am J Phys Med Rehabil.
265 Sato Y, Iwamoto J, Kanoko T, et al. (2005). Risedronate sodium therapy for prevention of hip fracture in men 65 years or older after stroke. Arch Intern Med.
266 Sato Y, Kanoko T, Satoh K, et al. (2005). The prevention of hip fracture with risedronate and ergocalciferol plus calcium supplementation in elderly women with Alzheimer disease: a randomized controlled trial. Arch Intern Med.
267 Sato Y, Iwamoto J, Kanoko T, et al. (2005). Risedronate therapy for prevention of hip fracture after stroke in elderly women. Neurology.
268 Sato Y, Iwamoto J, Kanoko T, et al. Alendronate and vitamin D2 for prevention of hip fracture in Parkinson's disease: A randomized controlled trial. Mov Disord 2006.
269 Sato Y, Honda Y, Iwamoto J. Etidronate for fracture prevention in amyotrophic lateral sclerosis: A randomized controlled trial. Bone 2006.
270 Schwarz C, Mitterbauer C, Heinze G, et al. (2004). Nonsustained effect of short-term bisphosphonate therapy on bone turnover three years after renal transplantation. Kidney international.
271 Shane E, Addesso V, Namerow PB, et al. (2004). Alendronate versus calcitriol for the prevention of bone loss after cardiac transplantation. N Engl J Med.
272 Sharma RK, Kaushal R, Gupta A, et al. (2002). Role of oral alendronate in prevention of bone loss in adult nephrotics on steroid treatment. Indian Journal of Nephrology.
273 Shimon I, Eshed V, Doolman R, et al. (2005). Alendronate for osteoporosis in men with androgen-repleted hypogonadism. Osteoporos Int.
274 Shiraki M, Kushida K, Fukunaga M, et al. (1999). A double-masked multicenter comparative study between alendronate and alfacalcidol in Japanese patients with osteoporosis. The Alendronate Phase III Osteoporosis Treatment Research Group. Osteoporos Int.
275 Shiraki M, Fukunaga M, Kushida K, et al. (2003). A double-blind dose-ranging study of risedronate in Japanese patients with osteoporosis (a study by the Risedronate Late Phase II Research Group). Osteoporos Int.
276 Siffledeen JS, Fedorak RN, Siminoski K, et al. (2005). Randomized trial of etidronate plus calcium and vitamin D for treatment of low bone mineral density in Crohn's disease. Clin Gastroenterol Hepatol.
277 Silberstein EB, Schnur W. (1992). Cyclic oral phosphate and etidronate increase femoral and lumbar bone mineral density and reduce lumbar spine fracture rate over three years. J Nucl Med.
278 Simon JA, Lewiecki EM, Smith ME, et al. (2002). Patient preference for once-weekly alendronate 70 mg versus once-daily alendronate 10 mg: a multicenter, randomized, open-label, crossover study. Clin Ther.
279 Smith MR MFZAFMHDSDKPFJ. Pamidronate to prevent bone loss during androgen-deprivation therapy for prostate cancer. The New England journal of medicine 2001;345(13):948–55.
280 Smith MR, Eastham J, Gleason DM, et al. (2003). Randomized controlled trial of zoledronic acid to prevent bone loss in men receiving androgen deprivation therapy for nonmetastatic prostate cancer. The Journal of urology.
281 Smith MR, Fallon MA, Lee H, et al. (2004). Raloxifene to prevent gonadotropin-releasing hormone agonist-induced bone loss in men with prostate cancer: a randomized controlled trial. The Journal of clinical endocrinology and metabolism.
282 Snyder PJ, Peachey H, Hannoush P, et al. (1999). Effect of testosterone treatment on bone mineral density in men over 65 years of age. J Clin Endocrinol Metab.
283 Stakkestad JA, Benevolenskaya LI, Stepan JJ, et al. (2003). Intravenous ibandronate injections given every three months: a new treatment option to prevent bone loss in postmenopausal women. Ann Rheum Dis.
284 Stefanick ML, Anderson GL, Margolis KL, et al. (2006). Effects of conjugated equine estrogens on breast cancer and mammography screening in postmenopausal women with hysterectomy. JAMA.
285 Steiniche T, Hasling C, Charles P, et al. (1991). The effects of etidronate on trabecular bone remodeling in postmenopausal spinal osteoporosis: a randomized study comparing intermittent treatment and an ADFR regime. Bone.
286 Storm T, Thamsborg G, Steiniche T, et al. (1990). Effect of intermittent cyclical etidronate therapy on bone mass and fracture rate in women with postmenopausal osteoporosis. N Engl J Med.
287 Storm T, Kollerup G, Thamsborg G, et al. (1996). Five years of clinical experience with intermittent cyclical etidronate for postmenopausal osteoporosis. J Rheumatol.
288 Struys A, Snelder AA, Mulder H. (1995). Cyclical etidronate reverses bone loss of the spine and proximal femur in patients with established corticosteroid-induced osteoporosis. Am J Med.
289 Tanko LB, McClung MR, Schimmer RC, et al. (2003). The efficacy of 48-week oral ibandronate treatment in postmenopausal osteoporosis when taken 30 versus 60 minutes before breakfast. Bone.
290 Tanko LB, Felsenberg D, Czerwinski E, et al. (2003). Oral weekly ibandronate prevents bone loss in postmenopausal women. Journal of internal medicine.
291 Tauchmanova L, Selleri C, Esposito M, et al. (2003). Beneficial treatment with risedronate in long-term survivors after allogeneic stem cell transplantation for hematological malignancies. Osteoporos Int.
292 Tauchmanova L, De Simone G, Musella T, et al. (2006). Effects of various antireabsorptive treatments on bone mineral density in hypogonadal young women after allogeneic stem cell transplantation. Bone Marrow Transplant.
293 Tekeoglu I, Adak B, Budancamanak M, et al. (2005). Comparison of cyclic and continuous calcitonin regimens in the treatment of postmenopausal osteoporosis. Rheumatol Int.
294 Terranova RLS. (1999). Treatment of post-menopausal osteoporosis using etidronate. Minerva Medica.
295 Thiebaud D, Burckhardt P, Melchior J, et al. (1994). Two years' effectiveness of intravenous pamidronate (APD) versus oral fluoride for osteoporosis occurring in the postmenopause. Osteoporos Int.
296 Thiebaud D, Burckhardt P, Kriegbaum H, et al. (1997). Three monthly intravenous injections of ibandronate in the treatment of postmenopausal osteoporosis. Am J Med.
297 Tiras MB, Noyan V, Yildiz A, et al. (2000). Comparison of different treatment modalities for postmenopausal patients with osteopenia: hormone replacement therapy, calcitonin and clodronate. Climacteric.
298 Tiras MB, Noyan V, Yildiz A, et al. (2000). Effects of alendronate and hormone replacement therapy, alone or in combination, on bone mass in postmenopausal women with osteoporosis: a prospective, randomized study. Hum Reprod.
299 Tonino RP, Meunier PJ, Emkey R, et al. (2000). Skeletal benefits of alendronate: 7-year treatment of postmenopausal osteoporotic women. Phase III Osteoporosis Treatment Study Group. J Clin Endocrinol Metab.
300 Torregrosa JV, Moreno A, Gutierrez A, et al. (2003). Alendronate for treatment of renal transplant patients with osteoporosis. Transplantation proceedings.
301 Tucci JR, Tonino RP, Emky RD, et al. (1996). Effect of three years of oral alendronate treatment in postmenopausal women with osteoproris. Am J Med.
302 Uchida S, Taniguchi T, Shimizu T, et al. (2005). Therapeutic effects of alendronate 35 mg once weekly and 5 mg once daily in Japanese patients with osteoporosis: a double-blind, randomized study. J Bone Miner Metab.
303 Ushiroyama T, Ikeda A, Sakai M, et al. (2001). Effects of the combined use of calcitonin and 1 alpha-hydroxycholecalciferol on vertebral bone loss and bone turnover in women with postmenopausal osteopenia and osteoporosis: a prospective study of long-term and continuous administration with low dose calcitonin. Maturitas.
304 Uusi-Rasi K, Kannus P, Cheng S, et al. (2003). Effect of alendronate and exercise on bone and physical performance of postmenopausal women: a randomized controlled trial. Bone.
305 Vogel VG, Costantino JP, Wickerham DL, et al. (2006). Effects of tamoxifen vs raloxifene on the risk of developing invasive breast cancer and other disease outcomes: the NSABP Study of Tamoxifen and Raloxifene (STAR) P-2 trial. Jama.
306 Wang C, Cunningham G, Dobs A, et al. (2004). Long-term testosterone gel (AndroGel) treatment maintains beneficial effects on sexual function and mood, lean and fat mass, and bone mineral density in hypogonadal men. The Journal of clinical endocrinology and metabolism.
307 Wasnich RD BYHDMMWMMAYJRPAPRPCCSAEPICSG. Changes in bone density and turnover after alendronate or estrogen withdrawal. Menopause (New York, NY) 2004;11(6 Pt):622–30.
308 Wassertheil-Smoller S, Hendrix SL, Limacher M, et al. (2003). Effect of estrogen plus progestin on stroke in postmenopausal women: the Women's Health Initiative: a randomized trial. JAMA.
309 Weinstein RS, Parfitt AM, Marcus R, et al. (2003). Effects of raloxifene, hormone replacement therapy, and placebo on bone turnover in postmenopausal women. Osteoporos Int.
310 Wimalawansa SJ. (1995). Combined therapy with estrogen and etidronate has an additive effect on bone mineral density in the hip and vertebrae: four-year randomized study. Am J Med.
311 Wimalawansa SJ. (1998). A four-year randomized controlled trial of hormone replacement and bisphosphonate, alone or in combination, in women with postmenopausal osteoporosis. Am J Med.
312 Worth H, Stammen D, Keck E. (1994). Therapy of steroid-induced bone loss in adult asthmatics with calcium, vitamin D, and a diphosphonate. Am J Respir Crit Care Med.
313 Yang TS, Tsan SH, Chen CR, et al. (1998). Effects of alendronate on bone turnover markers in early postmenopausal women. Zhonghua Yi Xue Za Zhi (Taipei).
314 Zegels B, Eastell R, Russell RG, et al. (2001). Effect of high doses of oral risedronate (20 mg/day) on serum parathyroid hormone levels and urinary collagen cross-link excretion in postmenopausal women with spinal osteoporosis. Bone.
315 Zehnder Y RSMDKHPRKMZGLK. Prevention of bone loss in paraplegics over 2 years with alendronate. Journal of bone and mineral research : the official journal of the American Society for Bone and Mineral Research 2004;19(7):1067–74.
316 Zein CO, Jorgensen RA, Clarke B, et al. (2005). Alendronate improves bone mineral density in primary biliary cirrhosis: a randomized placebo-controlled trial. Hepatology.
317 Zheng S, Wu Y, Zhang Z, et al. (2003). Effects of raloxifene hydrochloride on bone mineral density, bone metabolism and serum lipids in postmenopausal women: a randomized clinical trial in Beijing. Chin Med J (Engl).
318 Zheng SR WYZZYXHYZYCSDWLHEASJHKLJ. [A randomised clinical trial to study the effects of raloxifene hydrochloride on bone mineral density, biochemical markers of bone metabolism and serum lipids in postmenopausal women]. Zhonghua fu chan ke za zhi 2003;38( 4):226–9.
319 van Staa T, Abenhaim L, Cooper C. (1997). Upper gastrointestinal adverse events and cyclical etidronate. Am J Med.
320 van der Poest Clement E, van Engeland M, Ader H, et al. (2002). Alendronate in the prevention of bone loss after a fracture of the lower leg. Journal of bone and mineral research : the official journal of the American Society for Bone and Mineral Research.
321 von Tirpitz C, Klaus J, Steinkamp M, et al. (2003). Therapy of osteoporosis in patients with Crohn's disease: a randomized study comparing sodium fluoride and ibandronate. Alimentary pharmacology & therapeutics.

## Evidence Table C2. Evidence Tables for Randomized Controlled Trials

Evidence Table C2. Evidence Tables for Randomized Controlled Trials

Author, Year, Drug, Country, Trial name | Setting, Quality (Jadad score) | Eligibility criteria | Interventions (drug, dose, duration) | Interventions given to everyone | Run-in period Wash-out period | Allowed other medications/interventions | Method of outcome assessment Timing of assessment | Age (average/range) Gender Ethnicity | Screened/Eligible/Enrolled | Withdrawn/Lost to FU/Analyzed | Results - 1 | Results - 2 | Results - 3 | Results - 4 | Results - 5 | Results - 6 | Methods of adverse events assessment | Total withdrawals and Withdrawals due to adverse events | Screener notes | Long form notes
Agrawal S et al., 2006 ^1^ | Setting: Single center | Inclusion criteria: Men, Post-menopausal women NOS, ambulatory, cognitively intact | Placebo weekly vs. Risedronate 30 mg weekly | Calcium, Vitamin D | Run-in: None | | Assessed at baseline, 6 wk, 12 wk: Total fractures | 76/NR | 64/NR/60 | 7/0/53 | Number of people with fracture not reported | | | | | | Monitored, reported by patient | Placebo vs. Risedronate:
Risedronate | Jadad: 4 | Exclusion criteria: Carcinoma or suspected carcinoma, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Med known to affect skeleton, age <65, any significant lab abnormalities, Osteoporotic fracture within 2yrs | Duration: 3 months | | Wash-out: None | | | 77% male | | | | | | | | | | Withdrawals: 13.8%(4/29) vs. 9.7%(3/31)
US | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: 6.9%(2/29) vs. 6.5%(2/31)
Aris RM et al., 2000 ^2^ | Setting: Single center | Inclusion criteria: Men, Women otherwise undefined, Organ transplant, Cystic Fibrosis | Pamidronate 30 mg every 2 weeks vs. Control | Calcium, Vitamin D, Steroids | Run-in: None | | Assessed at baseline, 6 mo, 12 mo, 18 mo, 24 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Vertebral fracture | 28/18–38 | 44/37/37 | 3/0/34 | Number of people with fracture: long bone fractures at 24 months: Pamidronate vs. Control 18.8% vs. 33.3% OR = 0.48 (95% CI 0.11, 2.17) | Number of people with fracture: vertebral fractures at 24 months: Pamidronate vs. Control 18.8% vs. 5.6% OR = 3.43 (95% CI 0.44, 26.92) | | | | | Monitored, elicited by investigator | Control vs. Pamidronate: | | DROPOUTS DESCRIBED BUT NEVER STATED WHICH ARM THEY BELONG TO.
Pamidronate | Jadad: 3 | Exclusion criteria: Pregnancy, Renal insufficiency, Life expectancy <5 years, Graft Failure | Duration: 24 months | | Wash-out: None | | | 50% male | | | | | | | | | | Withdrawals: Not reported
US | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: Not reported
Black DM et al., 2007 ^3^ | Setting: Multi-center | Inclusion criteria: Post-menopausal women NOS, Osteoporosis score based on t-score and/or fractures and/or radiographic, Age > 65, age <=89 | Zoledronic acid 5 mg yearly vs Placebo yearly | Calcium, Vitamin D | Run-in: None | | Assessed at baseline, 6 mo, 12 mo, 24 mo, 36 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Hip frac., Vertebral frac., Total fractures | 73/NR | 18421/9977/7765 | NR/NR/7736 | Number of people with fracture: Any clinical fracture at 36 months: Zoledronic Acid 5mg vs Placebo 8.4% vs 12.8% OR = 0.63 (95% CI 0.54, 0.73) - NNT=22.7 (95% CI 17.2–33.5) | Number of people with fracture: Hip fracture at 36 months: Zoledronic Acid 5mg vs Placebo 1.4% vs 2.5% OR = 0.56 (95% CI 0.40, 0.78) - NNT=90.9 (95% CI 57.5–217.1) | Number of people with fracture: Nonvertebral fracture at 36 months: Zoledronic Acid 5mg vs Placebo 8.0% vs 10.7% OR = 0.73 (95% CI 0.62, 0.85) - NNT=37.0 (95% CI 24.8–73.3) | Number of people with fracture: morphometric vertebral fractures at 36 months: Zoledronic Acid 5mg vs Placebo 3.3% vs 10.9% OR = 0.32 (95% CI 0.26, 0.39) - NNT=13.2 (95% CI 11.2–15.9) | | | Monitored, elicited by investigator, reported by patient | Placebo vs Zoledronic acid: | | STUDY POPULATION=HIGH RISK FOR FRACTURE
Zoledronic acid | Jadad: 4 | Exclusion criteria: Bisphosphonates, Fluoride, Anabolic steroids, Corticoids/Glucocorticoids, Hypercalcemia, Hypocalcemia, previous PTH use, >2+ protein on urine dipstick, bisphosphonate use for >=48 weeks within 2 years prior to study, Growth Hormone use, strontium use, calculated creatinine clearance, 30.0 ml/min | Duration: 36 months | | Wash-out: None | | | 0% male | | | | Number of people with fracture: Multiple (>=2) morphometric vertebral fractures at 36 months: Zoledronic Acid 5mg vs Placebo 0.2% vs 2.3% OR = 0.16 (95% CI 0.10, 0.25) - NNT=47.6 (95% CI 37.5–65.3) | Number of people with fracture: clinical vertebral fracture at 36 months: Zoledronic Acid 5mg vs Placebo 0.5% vs 2.6% OR = 0.23 (95% CI 0.16, 0.35) - NNT=47.6 (95% CI 37.1–66.4) | | | | | Withdrawals: 15.7%(607/3876) vs 16.5%(641/3889)
US, Canada, Latin Amer, Western Europe, Eastern Europe, Australia/NZ, Asia | | | | | | | | 10110000 | | | | | | | | | | Withdrawals due to adverse events: 1.8%(70/3876) vs 2.1%(80/3889)
Horizon
Body JJ et al., 2002 ^4^ | Setting: Multi-center | Inclusion criteria: Post-menopausal >5 years, Osteoporosis T-score <= -2.5 hip, Osteoporosis T-score <= -2.5 spine | Placebo and PTH 40 ug daily vs. Placebo and Alendronate 10 mg daily | Calcium, Vitamin D | Run-in: 2 mo of Placebo, 2 mo of Control | | Assessed at baseline, 1 mo, 3 mo, 16 mo, 12 mo, 14 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Radial fracture | 66/NR | 265/149/149 | 37/1/143 | Number of people with fracture: nonvertebral fractures (ankle) at 14 months: PTH vs. Alendronate 0.0% vs. 2.7% OR = 0.13 (95% CI 0.01, 2.15) | Number of people with fracture: nonvertebral fractures (foot) at 14 months: PTH vs. Alendronate 1.4% vs. 1.4% OR = 1.00 (95% CI 0.06, 16.14) | Number of people with fracture: nonvertebral fractures (overall) at 14 months: PTH vs. Alendronate 4.1% vs. 13.7% OR = 0.31 (95% CI 0.10, 0.96) | Number of people with fracture: nonvertebral fractures (ribs) at 14 months: PTH vs. Alendronate 2.7% vs. 1.4% OR = 1.97 (95% CI 0.20, 19.20) | | | Monitored, elicited by investigator | Alendronate vs. PTH: | | STUDY ENDED EARLY SECONDARY ADVERSE EVENTS (OSTEOSARCOMA) IN RATS
Alendronate, PTH | Jadad: 4 | Exclusion criteria: Age > 85, Carcinoma or suspected carcinoma, Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Malabsorption syndrome, Urolithiasis, Bisphosphonates, Calcitonin, Fluoride, Androgen, Estrogen agonists (including estrogen), Anabolic steroids, Corticoids/Glucocorticoids, Alcohol Abuse, Allergy to PTH, age<30, LS spine abnormalities prohibiting DEXA, previous PTH use | Duration: 14 months | | Wash-out: None | | | 0% male | | | | Number of people with fracture: nonvertebral fractures (other - toe) at 14 months: PTH vs. Alendronate 0.0% vs. 4.1% OR = 0.13 (95% CI 0.01, 1.29) | Number of people with fracture: nonvertebral fractures (radius) at 14 months: PTH vs. Alendronate 0.0% vs. 4.1% OR = 0.13 (95% CI 0.01, 1.29) | | | | | Withdrawals: 21.9%(16/73) vs. 30.1%(22/73)
US, Canada, Latin America, Western Europe, Israel | | | | | | | | Caucasian, Hispanic, other | | | | | | | | | | Withdrawals due to adverse events: 9.6%(7/73) vs. 19.2%(14/73)
Bone HG et al., 2000 ^5^ | Setting: Multi-center | Inclusion criteria: Post-menopausal women NOS, Osteoporosis T-score <= -2.5 spine, Prior Hysterectomy | Placebo daily vs. Placebo and Alendronate 10 mg daily vs. Placebo and Estrogen 0.625 mg daily vs. Alendronate 10 mg and Estrogen 0.625 mg daily | Calcium | Run-in: None | | Assessed at baseline, 3 mo, 6 mo, 12 mo, 18 mo, 24 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Total fractures | 62/42–82 | NR/NR/425 | 105/17/395 | Number of people with fracture: any clinical fracture adverse effect (mostly nonvertebral fractures) at 24 months: Alendronate vs. Estrogen 5.0% vs. 7.0% OR = 0.77 (95% CI 0.26, 2.25) Alendronate vs. Placebo 5.0% vs. 8.0% OR = 0.65 (95% CI 0.16, 2.66) Alendronate+Estrogen vs. Alendronate 6.0% vs. 5.0% OR = 1.05 (95% CI 0.34, 3.30) Alendronate+Estrogen vs. Estrogen 6.0% vs. 7.0% OR = 0.81 (95% CI 0.31, 2.09) Alendronate+Estrogen vs. Placebo 6.0% vs. 8.0% OR = 0.68 (95% CI 0.18, 2.56) Estrogen vs. Placebo 7.0% vs. 8.0% OR = 0.86 (95% CI 0.25, 2.97) | | | | | | Bone histology | Alendronate vs. Estrogen vs. Alendronate, Estrogen vs. Placebo:
Alendronate, Estrogen | Jadad: 4 | Exclusion criteria: Cardiovascular disease, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Venous thromboembolic disease - Active, Venous thromboembolic disease - Ever, Bisphosphonates, Calcitonin, Fluoride, Vitamin D deficient, recent major upper GI mucosal erosive disease, Increased risk of breast cancer, Unexplained genital bleeding × 1 year, Fasting triglycerides >400mg/dL, Contraindication to HRT, HRT within last 6 months | Duration: 24 months | | Wash-out: None | | | 0% male | | | | | | | | | | Withdrawals: 15.2%(14/92) vs. 15.4%(22/143) vs. 13.6%(19/140) vs. 18.0%(9/50)
US | | | | | | | | Caucasian, other | | | | | | | | | | Withdrawals due to adverse events: 6.5%(6/92) vs. 9.8%(14/143) vs. 9.3%(13/140) vs. 10.0%(5/50)
ALENDRONATE ESTROGEN STUDY GRP
Bonnick S et al., 2006 ^6^ | Setting: Multi-center | Inclusion criteria: Post-menopausal >6 months, Osteoporosis T-score <= -2 NOS, Spine/Hip anatomy suitable for Dexa, ambulatory, Age >40 | Alendronate 70 mg weekly vs. Risedronate 35 mg weekly | Calcium, Vitamin D | Run-in: None | | Assessed at baseline, 3 mo, 6 mo, 12 mo, 24 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Total fractures | 65/NR | 1759/NR/1053 | 383/NR/750 | Number of people with fracture: clinical fractures at 24 months: Alendronate vs. Risedronate 8.3% vs. 8.2% OR = 1.01 (95% CI 0.62, 1.66) | | | | | | Monitored, elicited by investigator, reported by patient | Alendronate vs. Risedronate:
Alendronate, Risedronate | Jadad: 4 | Exclusion criteria: Metabolic bone disorder other than osteoporosis, Upper GI, Bisphosphonates, Fluoride, HRT, Estrogen agonists (including estrogen), Anabolic steroids, Corticoids/Glucocorticoids, Vitamin D deficient, previous PTH use, Hypocalcemia, Immunosuppressants | Duration: 24 months | | Wash-out: None | | | 0% male | | | | | | | | | | Withdrawals: 35.2%(183/520) vs. 37.5%(200/533)
US | | | | | | | | Caucasian, African-American, Asian, other | | | | | | | | | | Withdrawals due to adverse events: Not reported
FACT
Boutsen Y et al., 1997 ^7^ | Setting: Multi-center | Inclusion criteria: Men, Pre-menopausal women, Post-menopausal women NOS, Glucocorticoids >10mg | Pamidronate 90 mg daily and Pamidronate 30 mg every 3 months vs. Placebo | Calcium | Run-in: None | | Assessed at baseline, 3 mo, 6 mo, 9 mo, 12 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Vertebral fracture, Radiographic Vertebral Fractures | 61/NR | NR/NR/32 | 2/3/2027 | Number of people with fracture: vertebral fractures at 12 months: Pamidronate vs. Calcium 7.1% vs. 0.0% OR = 6.88 (95% CI 0.14, 347.7) | | | | | | Monitored | Calcium vs. Pamidronate: | | ARM 1 - PATIENT RECEIVED LOADING DOSE STUDY DURATION LASTED AS LONG AS PT WAS ON CORTICOSTEROIDS - VARIABLE
Pamidronate | Jadad: 3 | Exclusion criteria: Carcinoma or suspected carcinoma, Hypothyroidism, Hyperthyroidism, Hyperparathyroidism, Hepatic insufficiency, Renal insufficiency, Urolithiasis, Bisphosphonates, Fluoride, Previous Glucocorticoids | Duration: 1 day | | Wash-out: None | | | 18.5% male | | | | | | | | | | Withdrawals: 30.8%(4/13) vs. 35.7%(5/14)
Western Europe | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: 7.7%(1/13) vs. 0.0%(0/14)
Brown JP et al., 2002 ^8^ | Setting: Multi-center | Inclusion criteria: Post-menopausal >5 years, either spine T score <=-2.0 or hip T score <=-2.5, at least 3 evaluable lumbar vertebra without fx, age >50, ambulatory | Risedronate 5 mg daily vs. Risedronate 35 mg weekly vs. Risedronate 50 mg weekly | Calcium | Run-in: None | | Assessed at baseline, 3 mo, 6 mo, 12 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Vertebral fracture, Total fractures, Radiographic Vertebral Fractures | 68/NR | 4972/NR/1468 | 259/NR/1456 | Number of people with fracture: nonvertebral fractures at 24 months: Risedronate 35 mg vs. Risedronate 50 mg/wk 5.8% vs. 4.9% OR = 1.19 (95% CI 0.68, 2.08) Risedronate 5 mg vs. Risedronate 35 mg/wk 5.0% vs. 5.8% OR = 0.86 (95% CI 0.49, 1.50) Risedronate 5 mg vs. Risedronate 50 mg/wk 5.0% vs. 4.9% OR = 1.02 (95% CI 0.57, 1.83) | Number of people with fracture: vertebral fractures at 24 months: Risedronate 35 mg vs. Risedronate 50 mg/wk 1.0% vs. 0.4% OR = 2.40 (95% CI 0.54, 10.60) Risedronate 5 mg vs. Risedronate 35 mg/wk 1.3% vs. 1.0% OR = 1.21 (95% CI 0.37, 3.98) Risedronate 5 mg vs. Risedronate 50 mg/wk 1.3% vs. 0.4% OR = 2.80 (95% CI 0.70, 11.26) | | | | | Monitored, reported by patient | Risedronate 35 mg vs. Risedronate 5 mg vs. Risedronate 50 mg:
Risedronate | Jadad: 3 | Exclusion criteria: Med known to affect skeleton, LS spine abnormalities prohibiting DEXA | Duration: 12 months | | Wash-out: None | | | 0% male | | | | | | | | | | Withdrawals: 18.6%(90/485) vs. 16.0%(77/480) vs. 16.3%(80/491)
US, Canada | | | | | | | | Caucasian, other | | | | | | | | | | Withdrawals due to adverse events: 11.5%(56/485) vs. 11.9%(57/480) vs. 8.8%(43/491)
Campbell IA et al., 2004 ^9^ | Setting: Multi-center | Inclusion criteria: Men, Post-menopausal women NOS, Asthma or COPD, inhaled or oral glucocorticoids/steroids >=1yr | Control vs. Calcium 500 mg daily vs. Etidronate 400 mg daily for 14 days every 3 months vs. Etidronate 400 mg daily for 14 days every 3 months and Calcium 500 mg daily | Steroids | Run-in: None | | Assessed at baseline, 1 yr, 2 yr, 3 yr, 4 yr, 5 yr: BMD - DEXA-Hip, BMD - DEXA-Spine, Vertebral fracture, Total fractures, Radiographic Vertebral Fractures | 60/NR | NR/NR/352 | NR/51/349 | Number of people with fracture: new semi-quantitative vertebral fractures on spine radiographs at 60 months: Calcium vs. No treatment 12.9% vs. 15.8% OR = 0.80 (95% CI 0.35, 1.82) Etidronate vs. Calcium 11.1% vs. 12.9% OR = 0.84 (95% CI 0.33, 2.14) Etidronate vs. Etidronate +Calcium 11.1% vs. 8.0% OR = 1.44 (95% CI 0.52, 4.03) Etidronate vs. No treatment 11.1% vs. 15.8% OR = 0.67 (95% CI 0.28, 1.59) Etidronate+Calcium vs. Calcium 8.0% vs. 12.9% OR = 0.59 (95% CI 0.22, 1.56) Etidronate+Calcium vs. No treatment 8.0% vs. 15.8% OR = 0.48 (95% CI 0.20, 1.16) | Number of people with fracture: new symptomatic or semi-quantitative vertebral fractures at 60 months: Calcium vs. No treatment 17.6% vs. 20.0% OR = 0.86 (95% CI 0.41, 1.81) Etidronate vs. Calcium 16.0% vs. 17.6% OR = 0.89 (95% CI 0.40, 2.01) Etidronate vs. Etidronate +Calcium 16.0% vs. 15.9% OR = 1.01 (95% CI 0.44, 2.30) Etidronate vs. No treatment 16.0% vs. 20.0% OR = 0.77 (95% CI 0.36, 1.65) Etidronate+Calcium vs. Calcium 15.9% vs. 17.6% OR = 0.88 (95% CI 0.40, 1.96) Etidronate+Calcium vs. No treatment 15.9% vs. 20.0% OR = 0.76 (95% CI 0.36, 1.61) | | | | | Reported by patient | Etidronate, Calcium vs. Calcium vs. Etidronate vs. Placebo:
Etidronate | Jadad: 2 | Exclusion criteria: Hysterectomy, age <=50, age >=70 | Duration: 60 months | | Wash-out: None | | | 58% male | | | | Number of people with fracture: new symptomatic vertebral and non-vertebral fractures at 60 months: Calcium vs. No treatment 8.2% vs. 7.4% OR = 1.13 (95% CI 0.38, 3.35) Etidronate vs. Calcium 6.2% vs. 8.2% OR = 0.74 (95% CI 0.23, 2.38) Etidronate vs. Etidronate +Calcium 6.2% vs. 10.2% OR = 0.59 (95% CI 0.20, 1.75) Etidronate vs. No treatment 6.2% vs. 7.4% OR = 0.83 (95% CI 0.26, 2.68) Etidronate+Calcium vs. Calcium 10.2% vs. 8.2% OR = 1.27 (95% CI 0.45, 3.53) Etidronate+Calcium vs. No treatment 10.2% vs. 7.4% OR = 1.43 (95% CI 0.51, 3.98) | | | | | | Withdrawals: 35.2%(31/88) vs. 24.7%(21/85) vs. 21.0%(17/81) vs. 10.5%(10/95)
UK | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: 19.3%(17/88) vs. 5.9%(5/85) vs. 11.1%(9/81) vs. 0.0%(0/95)
Chapurlat RD et al., 2005 ^10^ | Setting: Multi-center | Inclusion criteria: Post-menopausal >2 years, T score<= -1.6 at the femoral neck | Placebo daily vs. Alendronate 5–10 mg daily | Calcium, Vitamin D | Run-in: None | | Assessed at baseline, 997 yr: Vertebral fracture, Radiographic Vertebral Fractures | NR/55–80 | NR/NR/1746 | NR/NR/1746 | Number of people with fracture not reported | | | | | | Monitored, elicited by investigator, reported by patient | Alendronate vs. Placebo:
[Hip] | Jadad: 4 | Exclusion criteria: Cardiovascular disease, Hypothyroidism, Hyperthyroidism, Hyperparathyroidism, Hepatic insufficiency, Renal insufficiency, Malabsorption syndrome, Upper GI, Bisphosphonates, Calcitonin, Fluoride, Estrogen agonists (including estrogen), age >= 80, age <=55, life expectancy =<3yrs | Duration: variable | | Wash-out: None | | | 0% male | | | | | | | | | | Withdrawals: Not reported
Alendronate | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: Not reported
US
FIT
Chapurlat RD et al., 2005 ^10^ | Setting: Multi-center | Inclusion criteria: Post-menopausal >2 years, T score<= -1.6 at the femoral neck | Placebo daily vs. Alendronate 5–10 mg daily | Calcium, Vitamin D | Run-in: None | | Assessed at baseline, 997 yr: Vertebral fracture, Radiographic Vertebral Fractures | NR/55–80 | NR/NR/1318 | NR/NR/1318 | Number of people with fracture not reported | | | | | | Monitored, elicited by investigator, reported by patient | Alendronate vs. Placebo:
[Spine] | Jadad: 4 | Exclusion criteria: Cardiovascular disease, Hypothyroidism, Hyperthyroidism, Hyperparathyroidism, Hepatic insufficiency, Renal insufficiency, Malabsorption syndrome, Upper GI, Bisphosphonates, Calcitonin, Fluoride, Estrogen agonists (including estrogen), age >= 80, age <=55, life expectancy =<3yrs | Duration: variable | | Wash-out: None | | | 0% male | | | | | | | | | | Withdrawals: Not reported
Alendronate | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: Not reported
US
FIT
Chesnut CH et al., 2004 ^11^ | Setting: Multi-center | Inclusion criteria: Post-menopausal >5 years, Osteoporosis T-score <= -2 spine, Osteoporosis/Fracture | Placebo daily vs. Ibandronate 2.5 mg daily vs. Placebo every other day for 12 doses followed by daily for the remainder of 3 mo and Ibandronate 20 mg every other day for 12 doses every 3 months | Calcium, Vitamin D | Run-in: None | | Assessed at baseline, 6 mo, 12 mo, 18 mo, 24 mo, 30 mo, 36 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Vertebral fracture, Total fractures, Symptomatic Vertebral Fractures, Radiographic Vertebral Fractures, Symptomatic Vertebral Fractures, Radiographic Vertebral Fractures | 69/55–80 | 18447/NR/2946 | NR/NR/2929 | Number of people with fracture: clinical osteoporotic nonvertebral fractures at 36 months: Ibandronate daily vs. Ibandronate intermittent 9.1% vs. 8.9% OR = 1.03 (95% CI 0.75, 1.40) Ibandronate daily vs. Placebo 9.1% vs. 8.2% OR = 1.00 (95% CI 0.73, 1.36) Ibandronate intermittent vs. Placebo 8.9% vs. 8.2% OR = 1.09 (95% CI 0.80, 1.50) | Number of people with fracture: clinical vertebral fractures at 36 months: Ibandronate daily vs. Ibandronate intermittent 2.3% vs. 2.3% OR = 1.00 (95% CI 0.55, 1.82) Ibandronate daily vs. Placebo 2.3% vs. 4.2% OR = 0.54 (95% CI 0.32, 0.88) - NNT=51.2 (95% CI 28.4–258.2) Ibandronate intermittent vs. Placebo 2.3% vs. 4.2% OR = 0.54 (95% CI 0.32, 0.88) - NNT=51.2 (95% CI 28.4–258.2) | | | | | Monitored | Ibandronate 2.5mg vs. Ibandronate 20mg vs. Placebo:
Ibandronate | Jadad: 4 | Exclusion criteria: Metabolic bone disorder other than osteoporosis, Renal insufficiency, Bisphosphonates, Fluoride, Med known to affect skeleton, Diseases known to affect skeleton, > 2 fractures lumbar spine, Contraindication to Ca or Vitamin D, Hypercalcemia, Hypocalcemia, age <=55, age >= 80, T score<-5.0 | Duration: 36 months | | Wash-out: None | | | 0% male | | | | Number of people with fracture: vertebral fractures at 36 months: Ibandronate daily vs. Ibandronate intermittent 3.8% vs. 4.0% OR = 0.95 (95% CI 0.60, 1.50) Ibandronate daily vs. Placebo 3.8% vs. 7.5% OR = 0.50 (95% CI 0.34, 0.73) - NNT=27.0 (95% CI 17.4–60.2) Ibandronate intermittent vs. Placebo 4.0% vs. 7.5% OR = 0.52 (95% CI 0.36, 0.77) - NNT=28.6 (95% CI 18.0–69.6) | | | | | | Withdrawals: 34.2%(334/977) vs. 32.8%(320/977) vs. 36.3%(354/975)
US, Canada, UK, Western Europe, Eastern Europe | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: 17.9%(175/977) vs. 18.2%(178/977) vs. 18.5%(180/975)
BONE
Coco M et al., 2003 ^12^ | Setting: Setting not reported | Inclusion criteria: Men, Women otherwise undefined, Organ transplant | Placebo vs. Pamidronate 60 mg at baseline and Pamidronate 30 mg at months 1, 2, 3 and 6 | Calcium, Vitamin D | Run-in: None | | Assessed at baseline, 1 mo, 2 mo, 3 mo, 4 mo, 5 mo, 6 mo, 7 mo, 8 mo, 9 mo, 10 mo, 11 mo, 12 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Hip fracture, Vertebral fracture | 44/NR | 112/98/72 | 13/NR/59 | Number of people with fracture: nonvertebral fractures at 12 months: Pamidronate vs. Control 0.0% vs. 0.0% OR = NC | Number of people with fracture: vertebral fractures at 12 months: Pamidronate vs. Control 3.2% vs. 7.1% OR = 0.45 (95% CI 0.04, 4.52) | | | | | NR | Calcium vs. Pamidronate: | | CALCITRIOL AND CALCIUM GIVEN TO MAINTAIN SERUM CALCIUM BETWEEN 8.5 AND 10.5 MG IDL
Pamidronate | Jadad: 2 | Exclusion criteria: Pregnancy | Duration: 12 months | | Wash-out: None | | | 50% male | | | | | | | | | | Withdrawals: 22.2%(8/36) vs. 13.9%(5/36)
US | | | | | | | | Caucasian, African-American, Hispanic, Asian | | | | | | | | | | Withdrawals due to adverse events: Not reported
Fisher B et al., 1998 ^13^ | Setting: Multi-center | Inclusion criteria: Women otherwise undefined, age >60 or age 35 to 59 with a 5 year risk of breast cancer of 1.66, life expectancy great than 10 years | Placebo daily vs. Tamoxifen 20 mg daily | | Run-in: None | | Assessed at 997 mo: Hip fracture, Radial fracture, Vertebral fracture, Total fractures, Symptomatic Vertebral Fractures | NR/NR | 98018/13954/13388 | NR/212/13175 | Number of people with fracture: hip fractures at 60 months: Tamoxifen vs. Placebo 0.2% vs. 0.3% OR = 0.56 (95% CI 0.28, 1.09) | Number of people with fracture: other lower radius fractures at 60 months: Tamoxifen vs. Placebo 1.0% vs. 1.0% OR = 1.05 (95% CI 0.74, 1.49) | Number of people with fracture: spine fractures at 60 months: Tamoxifen vs. Placebo 0.3% vs. 0.5% OR = 0.75 (95% CI 0.44, 1.27) | | | | Monitored, elicited by investigator, reported by patient | Placebo vs. Tamoxifen:
Tamoxifen | Jadad: 3 | Exclusion criteria: Pregnancy, Hepatic insufficiency, Renal insufficiency, Venous thromboembolic disease, Estrogen agonists (including estrogen), Progestin, Contraceptive, Breast Cancer, Abnormal CBC | Duration: variable | | Wash-out: None | | | 0% male | | | | Number of people with fracture: radius, collies fracture at 60 months: Tamoxifen vs. Placebo 0.2% vs. 0.3% OR = 0.62 (95% CI 0.32, 1.17) | | | | | | Withdrawals: 1.6%(108/6707) vs. 1.6%(104/6681)
US, Canada | | | | | | | | Caucasian, African-American, other | | | | | | | | | | Withdrawals due to adverse events: Not reported
NSABP-P1
Fukunaga M et al., 2002 ^14^ | Setting: Multi-center | Inclusion criteria: Men, Women otherwise undefined, Osteoporosis score based on t-score and/or fractures and/or radiographic | Risedronate 2.5 mg daily vs. Etidronate 200 mg daily for 14 days every 3 months | Calcium | Run-in: None | | Assessed at baseline, 12 wk, 24 wk, 36 wk, 48 wk: BMD - DEXA-Spine, Vertebral fracture, Total fractures, Radiographic Vertebral Fractures | 63/40–75 | 362/NR/235 | 32/3/209 | Number of people with fracture: nonvertebral fractures at 11.2 months: Etidronate vs. Risedronate 3.4% vs. 5.9% OR = 0.57 (95% CI 0.17, 1.91) | Number of people with fracture: vertebral fractures at 11.2 months: Etidronate vs. Risedronate 1.8% vs. 0.0% OR = 6.81 (95% CI 0.42, 110.0) | | | | | Monitored, reported by patient | Etidronate vs. Risedronate:
Etidronate, Risedronate | Jadad: 3 | Exclusion criteria: Age > 75, Carcinoma or suspected carcinoma, Cardiovascular disease, Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Upper GI, LS spine abnormalities prohibiting DEXA, Med known to affect skeleton, Drug Hypersensitivity, History of Radiotherapy | Duration: 11 months | | Wash-out: None | | | 1% male | | | | | | | | | | Withdrawals: 12.8%(15/117) vs. 16.9%(20/118)
Japan | | | | | | | | Asian | | | | | | | | | | Withdrawals due to adverse events: 6.0%(7/117) vs. 6.8%(8/118)
RESIDRONATE PHASE III RESEARCH
Gallagher JC et al., 2005 ^15^ | Setting: Multi-center | Inclusion criteria: Post-menopausal >5 years, Osteoporosis score based on t-score and/or fractures and/or radiographic | Placebo daily vs. PTH 20 ug daily | Calcium, Vitamin D | Run-in: None | | Assessed at baseline, 1 mo, 3 mo, 6 mo, 9 mo, 12 mo, 15 mo, 18 mo, 21 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Vertebral fracture, Radiographic Vertebral Fractures | 70/NR | 9347/NR/931 | NR/NR/NR | Number of people with fracture: nonvertebral fractures at 21 months: Teriparatide vs. Placebo 6.4% vs. 9.9% OR = 0.63 (95% CI 0.39, 1.00) | Number of people with fracture: vertebral fractures at 21 months: Teriparatide vs. Placebo 5.5% vs. 15.6% OR = 0.34 (95% CI 0.22, 0.54) - NNT=9.9 (95% CI 7.0–16.9) | | | | | Reported by patient | Placebo vs. PTH: | | 2 COUNTRIES WERE NOT REPORTED. STUDY DURATION MEDIAN IN ABSTRACT STATES 21 MOS WHEN IN THE METHODS STATES 19 MOS
PTH | Jadad: 2 | Exclusion criteria: Hepatic insufficiency, Renal insufficiency, Urolithiasis, nonambulatory, Alcohol Abuse, drug abuse, any medication that may alter bone and mineral metabolism, illnesses that affect bone and calcium metabolism | Duration: 19 months | | Wash-out: None | | | 0% male | | | | | | | | | | Withdrawals: Not reported
US, Canada, Latin Amer, Western Europe, Eastern Europe, Australia/NZ, Finland, Denmark, Italy, Israel | | | | | | | | Caucasian, other | | | | | | | | | | Withdrawals due to adverse events: Not reported
FRACTURE PREVENTION TRIAL
Garcia-Delgado I et al., 1997 ^16^ | Setting: Setting not reported | Inclusion criteria: Organ transplant, ambulatory, normal diet | Calcitonin 100 I.U. daily vs. Etidronate 400 mg daily for 14 days every 2.5 months vs. Vitamin D 32000 I.U. weekly | Calcium, Steroids, Azathioprine, Cyclosporine | Run-in: None | | Assessed at baseline, 6 mo, 12 mo, 18 mo: BMD - DEXA-Spine, Vertebral fracture, Radiographic Vertebral Fractures | 53/NR | NR/NR/40 | NR/NR/40 | Number of people with fracture: vertebral fractures at 18 months: Calcidiol vs. Calcitonin 0.0% vs. 30.8% OR = 0.10 (95% CI 0.01, 0.83) Etidronate vs. Calcidiol 21.4% vs. 0.0% OR = 8.08 (95% CI 0.76, 85.33) Etidronate vs. Calcitonin 21.4% vs. 30.8% OR = 0.63 (95% CI 0.12, 3.39) | | | | | | NR | Calcidiol vs. Calcitonin vs. Etidronate: | SPECIAL POPULATION CARDIAC TRANSPLANTS
Calcitonin, Etidronate | Jadad: 1 | Exclusion criteria: Med known to affect skeleton, Hypogonadism | Duration: 18 months | | Wash-out: None | | | 95% male | | | | | | | | | | Withdrawals: Not reported
Western Europe | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: Not reported
Grant AM et al., 2005 ^17^ | Setting: Multi-center | Inclusion criteria: Men, Post-menopausal women NOS, Osteoporosis/Fracture | Placebo daily vs. Calcium 1000 mg and Vitamin D 800 I.U. daily vs. Placebo and Vitamin D 800 I.U. daily vs. Placebo and Calcium 1000 mg daily | Steroids | Run-in: None | | Assessed at baseline, 62 mo: Hip fracture, Radial fracture, Vertebral fracture, Total fractures, Symptomatic Vertebral Fractures | 77/NR | 15024/8827/5292 | ./NR/. | Number of people with fracture: clinical vertebral fractures at 62 months: Calcium vs. Placebo 0.2% vs. 0.1% OR = 2.77 (95% CI 0.39, 19.65) Calcium vs. Vitamin D3+Calcium 0.2% vs. 0.0% OR = 7.37 (95% CI 0.77, 70.93) Vitamin D3 vs. Calcium 0.3% vs. 0.2% OR = 0.77 (95% CI 0.17, 3.39) Vitamin D3 vs. Placebo 0.3% vs. 0.1% OR = 3.30 (95% CI 0.57, 19.07) Vitamin D3+Calcium vs. Placebo 0.0% vs. 0.1% OR = 0.14 (95% CI 0.00, 6.96) Vitamin D3+Calcium vs. Vitamin D3 0.3% vs. 0.0% OR = 7.62 (95% CI 1.07, 54.16) | Number of people with fracture: confirmed fractures at 62 months: Calcium vs. Placebo 14.0% vs. 14.0% OR = 0.98 (95% CI 0.78, 1.21) Calcium vs. Vitamin D3+Calcium 14.0% vs. 14.0% OR = 1.03 (95% CI 0.83, 1.29) Calcium vs. Vitamin D3 16.0% vs. 14.0% OR = 1.12 (95% CI 0.90, 1.38) Vitamin D3 vs. Placebo 16.0% vs. 14.0% OR = 1.09 (95% CI 0.88, 1.35) Vitamin D3+Calcium vs. Placebo 14.0% vs. 14.0% OR = 0.94 (95% CI 0.76, 1.17) Vitamin D3+Calcium vs. Vitamin D3 14.0% vs. 16.0% OR = 0.87 (95% CI 0.70, 1.08) | Number of people with fracture: low-trauma fractures at 62 months: Calcium vs. Placebo 13.0% vs. 13.0% OR = 0.93 (95% CI 0.74, 1.17) Calcium vs. Vitamin D3+Calcium 13.0% vs. 13.0% OR = 1.00 (95% CI 0.80, 1.26) Vitamin D3 vs. Calcium 14.0% vs. 13.0% OR = 1.12 (95% CI 0.90, 1.40) Vitamin D3 vs. Placebo 14.0% vs. 13.0% OR = 1.05 (95% CI 0.84, 1.31) Vitamin D3+Calcium vs. Placebo 13.0% vs. 13.0% OR = 0.93 (95% CI 0.74, 1.17) Vitamin D3+Calcium vs. Vitamin D3 13.0% vs. 14.0% OR = 0.89 (95% CI 0.71, 1.11) | Number of people with fracture: other arm fractures at 62 months: Calcium vs. Placebo 2.5% vs. 3.7% OR = 0.68 (95% CI 0.44, 1.05) Calcium vs. Vitamin D3+Calcium 2.5% vs. 3.5% OR = 0.71 (95% CI 0.45, 1.11) Vitamin D3 vs. Calcium 3.6% vs. 2.5% OR = 1.43 (95% CI 0.92, 2.22) Vitamin D3 vs. Placebo 3.6% vs. 3.7% OR = 0.97 (95% CI 0.65, 1.46) Vitamin D3+Calcium vs. Placebo 3.5% vs. 3.7% OR = 0.96 (95% CI 0.63, 1.44) Vitamin D3+Calcium vs. Vitamin D3 3.4% vs. 3.7% OR = 0.98 (95% CI 0.65, 1.49) | Number of people with fracture: other leg and pelvic fractures at 62 months: Calcium vs. Placebo 3.1% vs. 4.1% OR = 0.77 (95% CI 0.51, 1.15) Calcium vs. Vitamin D3+Calcium 3.1% vs. 2.8% OR = 1.11 (95% CI 0.71, 1.74) Calcium vs. Vitamin D3 3.6% vs. 3.1% OR = 0.87 (95% CI 0.57, 1.33) Vitamin D3 vs. Placebo 3.6% vs. 4.1% OR = 0.88 (95% CI 0.59, 1.30) Vitamin D3+Calcium vs. Placebo 2.8% vs. 4.1% OR = 0.69 (95% CI 0.46, 1.05) Vitamin D3+Calcium vs. Vitamin D3 2.8% vs. 3.6% OR = 0.79 (95% CI 0.51, 1.21) | | Elicited by investigator, reported by patient | Calcium vs. Placebo vs. Vitamin D vs. Calcium, Vitamin D: | Vit D
Vitamin D | Jadad: 4 | Exclusion criteria: Carcinoma or suspected carcinoma, Nephrolithiasis, Bisphosphonates, Calcitonin, Calcium (includes antacids), Fluoride, HRT, SERMS, Vitamin D, age < 70, nonambulatory, mental condition that would preclude participation, Hypercalcemia, life expectancy <1/2 years, fracture associated with bone abnormality | Duration: variable | | Wash-out: None | | | 15% male | | | | Number of people with fracture: distal forearm fractures at 62 months: Calcium vs. Placebo 2.5% vs. 2.1% OR = 1.20 (95% CI 0.72, 2.00) Calcium vs. Vitamin D3+Calcium 2.5% vs. 2.5% OR = 1.00 (95% CI 0.61, 1.62) Calcium vs. Vitamin D3 2.5% vs. 2.5% OR = 1.03 (95% CI 0.63, 1.67) Vitamin D3 vs. Placebo 2.5% vs. 2.1% OR = 1.17 (95% CI 0.71, 1.95) Vitamin D3+Calcium vs. Placebo 2.5% vs. 2.1% OR = 1.21 (95% CI 0.73, 2.01) Vitamin D3+Calcium vs. Vitamin D3 2.5% vs. 2.5% OR = 1.03 (95% CI 0.63, 1.68) | Number of people with fracture: new fractures at 62 months: Calcium vs. Placebo 14.4% vs. 14.7% OR = 0.98 (95% CI 0.79, 1.21) Calcium vs. Vitamin D3+Calcium 14.0% vs. 14.0% OR = 1.03 (95% CI 0.83, 1.28) Vitamin D3 vs. Calcium 15.8% vs. 14.4% OR = 0.90 (95% CI 0.73, 1.11) Vitamin D3 vs. Placebo 15.8% vs. 14.7% OR = 1.09 (95% CI 0.88, 1.34) Vitamin D3+Calcium vs. Placebo 14.0% vs. 15.0% OR = 0.95 (95% CI 0.76, 1.18) Vitamin D3+Calcium vs. Vitamin D3 14.0% vs. 16.0% OR = 0.88 (95% CI 0.71, 1.08) | Number of people with fracture: other fractures at 62 months: Calcium vs. Placebo 0.5% vs. 0.5% OR = 1.19 (95% CI 0.40, 3.53) Calcium vs. Vitamin D3+Calcium 0.5% vs. 0.2% OR = 2.22 (95% CI 0.64, 7.70) Vitamin D3 vs. Calcium 0.6% vs. 0.5% OR = 1.12 (95% CI 0.40, 3.08) Vitamin D3 vs. Placebo 0.6% vs. 0.5% OR = 1.32 (95% CI 0.46, 3.78) Vitamin D3+Calcium vs. Placebo 0.2% vs. 0.5% OR = 0.52 (95% CI 0.14, 1.93) Vitamin D3+Calcium vs. Vitamin D3 0.2% vs. 0.6% OR = 0.41 (95% CI 0.13, 1.35) | Number of people with fracture: proximal femur fractures at 62 months: Calcium vs. Placebo 3.7% vs. 3.1% OR = 1.22 (95% CI 0.80, 1.86) Calcium vs. Vitamin D3+Calcium 3.7% vs. 3.5% OR = 1.06 (95% CI 0.71, 1.60) Calcium vs. Vitamin D3 3.7% vs. 3.5% OR = 1.07 (95% CI 0.71, 1.06) Vitamin D3 vs. Placebo 3.5% vs. 3.1% OR = 1.14 (95% CI 0.75, 1.75) Vitamin D3+Calcium vs. Placebo 3.5% vs. 3.1% OR = 1.15 (95% CI 0.75, 1.76) Vitamin D3+Calcium vs. Vitamin D3 3.5% vs. 3.5% OR = 1.01 (95% CI 0.67, 1.52) | | | Withdrawals: 1.7%(22/1311) vs. 1.1%(14/1332) vs. 1.1%(15/1343) vs. 1.2%(16/1306)
UK | | | | | | | | Caucasian, other | | | | | | | | | | Withdrawals due to adverse events: Not reported
Greenspan SL et al., 2003 ^18^ | Setting: Single center | Inclusion criteria: Women otherwise undefined, Age > 65 | Placebo vs. Placebo and Estrogen 0.625 mg daily vs. Placebo and Alendronate 10 mg daily vs. Alendronate 10 mg and Estrogen 0.625 mg daily | Calcium, Vitamin D | Run-in: 3 mo of Placebo for Subjects that completed run-in randomized, 3 mo of Estrogen for Subjects that completed run-in randomized, 3 mo of Calcium for Subjects that completed run-in randomized | Medroxyprogesterone (if necessary) | Assessed at baseline, 0 mo, 6 mo, 12 mo, 18 mo, 24 mo, 30 mo, 36 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Total fractures | 72/65–90 | 573/548/373 | 26/8/373 | Number of people with fracture: clinical fractures at 36 months: Alendronate vs. Estrogen 8.0% vs. 5.0% OR = 1.43 (95% CI 0.44, 4.58) Alendronate vs. Placebo 8.0% vs. 10.0% OR = 0.76 (95% CI 0.27, 2.12) Alendronate+Estrogen vs. Alendronate 4.0% vs. 8.0% OR = 0.56 (95% CI 0.16, 1.87) Alendronate+Estrogen vs. Estrogen 4.0% vs. 5.0% OR = 0.78 (95% CI 0.21, 2.98) Alendronate+Estrogen vs. Placebo 4.0% vs. 10.0% OR = 0.43 (95% CI 0.14, 1.34) Estrogen vs. Placebo 5.0% vs. 10.0% OR = 0.54 (95% CI 0.18, 1.60) | | | | | | NR | Alendronate vs. Estrogen vs. Alendronate, Estrogen vs. Placebo:
Alendronate, Estrogen | Jadad: 5 | Exclusion criteria: Carcinoma or suspected carcinoma, Hyperthyroidism, Hyperparathyroidism, Hepatic insufficiency, Renal insufficiency, Anticonvulsants, Bisphosphonates, Calcitonin, Hormone use, Corticoids/Glucocorticoids, Med known to affect skeleton, Contraindication to HRT, Contraindication to alendronate, BMD hip T score >0.0 | Duration: 36 months | | Wash-out: None | | | 0% male | | | | | | | | | | Withdrawals: 8.6%(8/93) vs. 9.7%(9/93) vs. 9.6%(9/94) vs. 10.8%(10/93)
US | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: 2.2%(2/93) vs. 2.2%(2/93) vs. 0.0%(0/94) vs. 2.2%(2/93)
Greenspan SL et al., 2006 ^19^ | Setting: Single center | Inclusion criteria: Post-menopausal women NOS, Breast cancer, Post chemotherapy with or without tamoxifen | Risedronate 35 mg weekly vs. Placebo weekly | Calcium, Vitamin D | Run-in: None | | Assessed at baseline, 6 mo, 12 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Total fractures, Symptomatic Vertebral Fractures | 50/NR | 106/94/87 | 5/4/1987 | Number of people with fracture: fractures at 12 months: Risedronate vs. Placebo 4.7% vs. 0.0% OR = 7.75 (95% CI 0.48, 125.9) | | | | | | Reported by patient | Placebo vs. Risedronate:
Risedronate | Jadad: 5 | Exclusion criteria: Carcinoma or suspected carcinoma, Hyperparathyroidism, Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Malabsorption syndrome, age <18, Stage IV breast cancer, any medication that may alter bone and mineral metabolism | Duration: 12 months | | Wash-out: None | | | 0% male | | | | | | | | | | Withdrawals: 2.3%(1/44) vs. 9.3%(4/43)
US | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: Not reported
Grotz W et al., 2001 ^20^ | Setting: Single center | Inclusion criteria: Men, Pre-menopausal women, Post-menopausal women NOS, Organ transplant | Control vs. Ibandronate 1 mg daily for 1 day and Ibandronate 2 mg every 3 months for 9 months | Calcium, Estrogen, Vitamin D, Steroids | Run-in: None | | Assessed at baseline, 6 mo, 12 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Vertebral fracture, Total fractures, Radiographic Vertebral Fractures, Symptomatic Vertebral Fractures | 43/20–60 | 114/98/80 | 8/0/72 | Number of people with fracture: arm fractures at 12 months: Ibandronate vs. Control 2.5% vs. 2.5% OR = 1.00 (95% CI 0.06, 16.27) | Number of people with fracture: vertebral fractures at 12 months: Ibandronate vs. Control 2.5% vs. 2.5% OR = 1.00 (95% CI 0.06, 16.27) | | | | | Monitored, reported by patient | Ibandronate vs. Placebo: | | IBANDRONATE GROUP GIVEN ONE DOSE OF 1 MG PRIOR TO TRANSPLANT THEN 2 MG AT 3, 6 AND 9 MONTHS
Ibandronate | Jadad: 2 | Exclusion criteria: Kidney Pancreas Transplant | | | Wash-out: None | | | 67% male | | | | | | | | | | Withdrawals: 10.0%(4/40) vs. 10.0%(4/40)
Germany | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: 7.5%(3/40) vs. 5.0%(2/40)
Guanabens N et al., 2003 ^21^ | Setting: Setting not reported | Inclusion criteria: Women otherwise undefined, Osteopenia T-score <= -1.0 NOS, Primary Biliary Cirrhosis | Etidronate 400 mg daily for 14 days every 3 months vs. Alendronate 10 mg daily | Calcium, Vitamin D, Ursodeoxycholic Acid | Run-in: None | | Assessed at baseline, 6 mo, 12 mo, 18 mo, 24 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Vertebral fracture, Total fractures, Radiographic Vertebral Fractures | 59/41–77 | NR/NR/32 | 6/0/26 | Number of people with fracture: nonvertebral fractures at 24 months: Alendronate vs. Etidronate 15.4% vs. 7.7% OR = 2.06 (95% CI 0.19, 21.85) | Number of people with fracture: vertebral fractures at 24 months: Alendronate vs. Etidronate 0.0% vs. 0.0% OR = NC | | | | | NR | Alendronate vs. Etidronate: | #4 PRIMARY BILIARY CIRRHOSIS
Alendronate, Etidronate | Jadad: 3 | Exclusion criteria: Renal insufficiency, Upper GI, Bisphosphonates, Fluoride, Estrogen agonists (including estrogen), Corticoids/Glucocorticoids, Bilirubin >10mg/dL | Duration: 24 months | | Wash-out: None | | | 0% male | | | | | | | | | | Withdrawals: 18.8%(3/16) vs. 18.8%(3/16)
Western Europe | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: 6.3%(1/16) vs. 18.8%(3/16)
Harris ST et al., 2004 ^22^ | Setting: Multi-center | Inclusion criteria: Post-menopausal >5 years, either spine T score <=-2.0 or hip T score <=-2.5, at least 3 evaluable lumbar vertebra without fx, age >50, ambulatory | Risedronate 5 mg daily vs. Risedronate 35 mg weekly vs. Risedronate 50 mg weekly | Calcium | Run-in: None | | Assessed at baseline, 3 mo, 6 mo, 12 mo, 24 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Vertebral fracture, Total fractures, Radiographic Vertebral Fractures | 68/NR | 4972/NR/1468 | 341/24/1456 | Number of people with fracture: vertebral fractures at 24 months: Risedronate 35 mg/wk vs. Risedronate 50 mg/wk 1.5% vs. 1.7% OR = 0.90 (95% CI 0.30, 2.68) Risedronate 5 mg vs. Risedronate 35 mg/wk 2.9% vs. 1.5% OR = 1.92 (95% CI 0.75, 4.88) Risedronate 5 mg vs. Risedronate 50 mg/wk 2.9% vs. 1.7% OR = 1.74 (95% CI 0.70, 4.32) | | | | | | Monitored, reported by patient | Risedronate 35 mg once a week vs. Risedronate 50mg once a week vs. Risedronate 5mg daily:
Risedronate | Jadad: 3 | Exclusion criteria: Med known to affect skeleton, LS spine abnormalities prohibiting DEXA | Duration: 24 months | | Wash-out: None | | | 0% male | | | | | | | | | | Withdrawals: 23.7%(115/485) vs. 22.8%(112/491) vs. 21.3%(102/480)
US, Canada | | | | | | | | Caucasian, other | | | | | | | | | | Withdrawals due to adverse events: 15.5%(75/485) vs. 12.2%(60/491) vs. 15.6%(75/480)
Hay JE et al., 2001 ^23^ | Setting: Single center | Inclusion criteria: Men, Pre-menopausal women, Post-menopausal women NOS, Organ transplant | Control vs. SQ Calcitonin 100 MRC units daily | Calcium, Vitamin D, Steroids | Run-in: None | | Assessed at baseline, 4 mo, 12 mo: BMD - DEXA-Spine, Vertebral fracture, Radiographic Vertebral Fractures | 51/NR | NR/NR/63 | NR/NR/55 | Number of people with fracture: other fractures at 12 months: Salmon calcitonin vs. No therapy 4.0% vs. 6.0% OR = 0.36 (95% CI 0.05, 2.71) | Number of people with fracture: rib fractures at 12 months: Salmon calcitonin vs. No therapy 12.0% vs. 3.0% OR = 3.00 (95% CI 0.40, 22.53) | Number of people with fracture: other fractures at 4 months: Salmon calcitonin vs. No therapy 4.0% vs. 6.0% OR = 0.52 (95% CI 0.05, 5.22) | Number of people with fracture: spine fractures at 4 months: Salmon calcitonin vs. No therapy 15.0% vs. 21.0% OR = 0.65 (95% CI 0.17, 2.51) | | | Monitored, reported by patient | Placebo vs. Calcitonin: | Only patients with low vitamin D levels, hypocalcemia, increased PTH or low urinary, calcium in regimen, vitamin D in both arms
Calcitonin | Jadad: 1 | Exclusion criteria: Hypothyroidism, Hyperthyroidism, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Anticonvulsants, Hormone use, Corticoids/Glucocorticoids, Med known to affect skeleton, Survived 6mos after liver transplant | Duration: 6 months | | Wash-out: None | | | 38% male | | | | Number of people with fracture: spine fractures at 12 months: Salmon calcitonin vs. No therapy 19.0% vs. 27.0% OR = 0.58 (95% CI 0.17, 1.99) | Number of people with fracture: rib fractures at 4 months: Salmon calcitonin vs. No therapy 4.0% vs. 7.0% OR = 0.52 (95% CI 0.05, 5.22) | | | | | Withdrawals: 5.9%(2/34) vs. 24.1%(7/29)
US | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: 2.9%(1/34) vs. 10.3%(3/29)
Hizmetli S et al., 1998 ^24^ | Setting: Single center | Inclusion criteria: Post-menopausal women NOS, Osteoporosis T-score <= -2.5 NOS | Control vs. Calcitonin 50 I.U. daily vs. Calcitonin 100 I.U. daily | | | | Assessed at baseline, 6 mo, 12 mo, 24 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Vertebral fracture, Radiographic Vertebral Fractures | 58/NR | NR/NR/107 | 20/NR/87 | Number of people with fracture not reported | | | | | | NR | Calcitonin 100 iu & calcium + Vitamin D 1000 mg/d vs. Calcitonin 50 iu & calcium + Vitamin D 1000 mg/d vs. Calcium, Vitamin D:
Calcitonin | Jadad: 1 | Exclusion criteria: Med known to affect skeleton, Secondary Osteoporosis | Duration: 24 months | | | | | 0% male | | | | | | | | | | Withdrawals: 14.6%(6/41) vs. 17.1%(6/35) vs. 25.8%(8/31)
Turkey | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: Not reported
Hochberg MC et al., 2005 ^25^ | Setting: Multi-center | Inclusion criteria: Post-menopausal >2 years, T score<= -1.6 at the femoral neck | Placebo daily vs. Alendronate 5–10 mg daily | Calcium, Vitamin D | Run-in: None | | Assessed at baseline, 997 yr: Hip fracture, Radial fracture, Vertebral fracture, Radiographic Vertebral Fractures | NR/55–80 | NR/NR/3658 | NR/NR/3658 | Number of people with fracture not reported | | | | | | Monitored, elicited by investigator, reported by patient | Alendronate vs. Placebo: | subgroup analyses
Alendronate | Jadad: 4 | Exclusion criteria: Cardiovascular disease, Hypothyroidism, Hyperthyroidism, Hyperparathyroidism, Hepatic insufficiency, Renal insufficiency, Malabsorption syndrome, Upper GI, Bisphosphonates, Calcitonin, Fluoride, Estrogen agonists (including estrogen), age >= 80, age <=55, life expectancy =<3yrs | Duration: variable | | Wash-out: None | | | 0% male | | | | | | | | | | Withdrawals: Not reported
US | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: Not reported
FIT
Hooper MJ et al., 2005 ^26^ | Setting: Multi-center | Inclusion criteria: Post-menopausal >6 months, Osteoporosis T-score <= -2.5 spine, FSH>= 50, postmenopausal < 3 years | Placebo daily vs. Risedronate 2.5 mg daily vs. Risedronate 5 mg daily | Calcium | Run-in: None | | Assessed at baseline, 3 mo, 6 mo, 12 mo, 18 mo, 24 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Vertebral fracture, Symptomatic Vertebral Fractures, Radiographic Vertebral Fractures | 53/42–63 | NR/NR/383 | 84/1/381 | Number of people with fracture: nonvertebral fractures at 24 months: Risedronate 2.5 mg vs. Placebo 2.4% vs. 4.8% OR = 0.50 (95% CI 0.13, 1.90) Risedronate 2.5 mg vs. Risedronate 5 mg 2.4% vs. 3.9% OR = 0.60 (95% CI 0.15, 2.44) Risedronate 5 mg vs. Placebo 3.9% vs. 4.8% OR = 0.83 (95% CI 0.25, 2.76) | Number of people with fracture: vertebral fractures at 24 months: Risedronate 2.5 mg vs. Placebo 8.7% vs. 8.3% OR = 1.09 (95% CI 0.45, 2.66) Risedronate 2.5 mg vs. Risedronate 5 mg 8.7% vs. 7.7% OR = 1.13 (95% CI 0.46, 2.75) Risedronate 5 mg vs. Placebo 7.7% vs. 8.3% OR = 0.97 (95% CI 0.39, 2.40) | | | | | Elicited by investigator, reported by patient | Placebo vs. Risedronate 2.5mg/d vs. Risedronate 5mg/d: | | VERTEBRAL AND NONVERTEBRAL FRACTURES WERE MONITORED AS ADVERSE EVENTS
Risedronate | Jadad: 3 | Exclusion criteria: Hyperthyroidism, Hyperparathyroidism, Metabolic bone disorder other than osteoporosis, Serum estradiol >20, Med known to affect skeleton | Duration: 24 months | | Wash-out: None | | | 0% male | | | | | | | | | | Withdrawals: 26.2%(33/126) vs. 21.9%(28/128) vs. 20.2%(26/129)
Australia/NZ | | | | | | | | Caucasian, other | | | | | | | | | | Withdrawals due to adverse events: 6.3%(8/126) vs. 9.4%(12/128) vs. 5.4%(7/129)
Hosking D et al., 2003 ^27^ | Setting: Multi-center | Inclusion criteria: Post-menopausal >2 years, Osteoporosis T-score <= -2.5 hip, Osteoporosis T-score <= -2.5 spine, Hip and Spine Dexa <-2.0 | Placebo daily and Placebo2 dosage not applicable weekly vs. Placebo weekly and Risedronate 5 mg daily vs. Placebo daily and Alendronate 70 mg weekly | Calcium, Vitamin D | Run-in: None | | Assessed at baseline, 1 mo, 3 mo, 6 mo, 12 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Total fractures, Symptomatic Vertebral Fractures | 69/NR | 1036/NR/549 | 107/3/NR | Number of people with fracture: vertebral or nonvertebral fractures at 12 months: Alendronate vs. Placebo 2.7% vs. 1.9% OR = 1.52 (95% CI 0.34, 6.67) Alendronate vs. Risedronate 2.7% vs. 2.7% OR = 1.04 (95% CI 0.33, 3.27) Risedronate vs. Placebo 2.7% vs. 1.9% OR = 1.47 (95% CI 0.33, 6.52) | | | | | | Monitored, elicited by investigator, reported by patient | Alendronate vs. Placebo vs. Risedronate:
Alendronate, Risedronate | Jadad: 5 | Exclusion criteria: Hypothyroidism, Hyperthyroidism, Hypoparathyroidism, Metabolic bone disorder other than osteoporosis, Bisphosphonates, Fluoride, HRT, Estrogen agonists (including estrogen), Corticoids/Glucocorticoids, LS spine abnormalities prohibiting DEXA, Vitamin D deficient, Severe Upper GI symptoms, Severe Osteoporosis, age >90, age <60, Abnormal Urinary Calcium | Duration: 12 months | | Wash-out: None | | | 0% male | | | | | | | | | | Withdrawals: 21.5%(47/219) vs. 17.6%(19/108) vs. 19.8%(44/222)
UK, Western Europe, Brazil | | | | | | | | Caucasian, other | | | | | | | | | | Withdrawals due to adverse events: 14.2%(31/219) vs. 11.1%(12/108) vs. 14.0%(31/222)
Ishida Y et al., 2004 ^28^ | Setting: Single center | Inclusion criteria: Post-menopausal >5 years, Osteoporosis T-score <= -2.5 NOS, Osteoporosis/Fracture, ambulatory | Control daily vs. Estrogen 0.625 mg daily vs. Etidronate 200 mg daily for 2 weeks every 12 weeks vs. Calcitonin 20 I.U. weekly vs. Vitamin D 1 ug daily vs. Vitamin K 45 mg daily | | Run-in: None | Medroxyprogesterone | Assessed at baseline, 3 mo, 6 mo, 9 mo, 12 mo, 15 mo, 18 mo, 21 mo, 24 mo: Hip fracture, Radial fracture, Vertebral fracture | NR/50–75 | 739/NR/396 | 24/11/NR | Number of people with fracture: vertebral fractures at 24 months: Alfacalcidol vs. Control (no treatment) 16.7% vs. 25.8% OR = 0.58 (95% CI 0.25, 1.34) Alfacalcidol vs. Vitamin K 16.7% vs. 13.6% OR = 1.26 (95% CI 0.49, 3.26) Calcitonin vs. Alfacalcidol 12.1% vs. 16.7% OR = 0.69 (95% CI 0.26, 1.83) Calcitonin vs. Control (no treatment) 12.1% vs. 25.8% OR = 0.41 (95% CI 0.17, 0.99) - NNT=7.3 (95% CI 3.7–211.9) Calcitonin vs. Estrogen+Medroxyprogesterone 12.1% vs. 10.6% OR = 1.16 (95% CI 0.40, 3.39) Calcitonin vs. Vitamin K 12.1% vs. 13.6% OR = 0.87 (95% CI 0.32, 2.41) Control (no treatment) vs. Vitamin K 25.8% vs. 13.6% OR = 2.14 (95% CI 0.91, 5.03) Estrogen+Medroxyprogesterone vs. Alfacalcidol 10.6% vs. 16.7% OR = 0.60 (95% CI 0.22, 1.62) Estrogen+Medroxyprogesterone vs. Control (no treatment) 10.6% vs. 25.8% OR = 0.36 (95% CI 0.15, 0.88) - NNT=6.6 (95% CI 3.6–44.5) Estrogen+Medroxyprogesterone vs. Vitamin K 10.6% vs. 13.6% OR = 0.75 (95% CI 0.27, 2.14) Etidronate vs. Alfacalcidol 12.1% vs. 16.7% OR = 0.69 (95% CI 0.26, 1.83) Etidronate vs. Calcitonin 12.1% vs. 12.1% OR = 1.00 (95% CI 0.35, 2.83) Etidronate vs. Control (no treatment) 12.1% vs. 25.8% OR = 0.41 (95% CI 0.17, 0.99) - NNT=7.3 (95% CI 3.7–211.9) Etidronate vs. Estrogen+Medroxyprogesterone 12.1% vs. 10.6% OR = 1.16 (95% CI 0.40, 3.39) Etidronate vs. Vitamin K 12.1% vs. 13.6% OR = 0.87 (95% CI 0.32, 2.41) | | | | | | NR | Vitamin D vs. Calcitonin vs. Control vs. Etidronate vs. Estrogen vs. Vitamin K:
Calcitonin, Estrogen, Etidronate | Jadad: 2 | Exclusion criteria: Age > 75, Carcinoma or suspected carcinoma, Metabolic bone disorder other than osteoporosis, Med known to affect skeleton, bilateral hip fractures, mental condition that would preclude participation | Duration: 24 months | | Wash-out: None | | | 0% male | | | | | | | | | | Withdrawals: 4.5%(3/66) vs. 6.1%(4/66) vs. 9.1%(6/66) vs. 6.1%(4/66) vs. 6.1%(4/66) vs. 4.5%(3/66)
Japan | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: 0.0%(0/66) vs. 0.0%(0/66) vs. 0.0%(0/66) vs. 1.5%(1/66) vs. 4.5%(3/66) vs. 0.0%(0/66)
YAMAGUCHI OP PREVENTION STUDY
Iwamoto J et al., 2003 ^29^ | Setting: Multi-center | Inclusion criteria: Women otherwise undefined, Osteoporosis/Fracture, Back Pain | Etidronate 200 mg daily for 14 days every 3 months vs. Alendronate 5 mg daily | | Run-in: None | | Assessed at baseline, 3 mo, 6 mo: Vertebral fracture, Radiographic Vertebral Fractures | 74/63–84 | NR/NR/50 | 0/0/50 | Number of people with fracture: vertebral fractures at 6 months: Alendronate vs. Etidronate 0.0% vs. 4.0% OR = 0.14 (95% CI 0.00, 6.82) | | | | | | NR | Alendronate vs. Etidronate:
Alendronate, Etidronate | Jadad: 1 | Exclusion criteria: Metabolic bone disorder other than osteoporosis, HRT, Estrogen agonists (including estrogen), Med known to affect skeleton | Duration: 6 months | | Wash-out: None | | | 0% male | | | | | | | | | | Withdrawals: 0.0%(0/25) vs. 0.0%(0/25)
Japan | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: 0.0%(0/25) vs. 0.0%(0/25)
Jackson RD et al., 2006 ^30^ | Setting: Multi-center | Inclusion criteria: Post-menopausal women NOS | Placebo daily vs. Calcium 1000 mg and Vitamin D 400 I.U. daily | Calcium, Estrogen, Vitamin D | Run-in: None | | Assessed at 997 yr: BMD - DEXA-Hip, BMD - DEXA-Spine, Hip fracture, Radial fracture, Vertebral fracture, Total fractures, Symptomatic Vertebral Fractures | 62/50–79 | 68132/62528/36282 | 2235/296/36282 | Number of people with fracture: clinical vertebral fractures at 84 months: Calcium+Vitamin D vs. Placebo 1.0% vs. 1.0% OR = 0.91 (95% CI 0.75, 1.12) | Number of people with fracture: hip fractures at 84 months: Calcium+Vitamin D vs. Placebo 1.0% vs. 1.0% OR = 0.87 (95% CI 0.71, 1.07) | Number of people with fracture: total fractures at 84 months: Calcium+Vitamin D vs. Placebo 12.0% vs. 12.0% OR = 0.97 (95% CI 0.91, 1.03) | | | | Monitored, elicited by investigator, reported by patient | Calcium, Vitamin D vs. Placebo:
Calcium, Vitamin D | Jadad: 4 | Exclusion criteria: Nephrolithiasis, Vitamin D, Corticoids/Glucocorticoids, age >= 80, Hypercalcemia, age <=50, life expectancy =<3yrs | Duration: variable | | Wash-out: None | | | 0% male | | | | Number of people with fracture: lower arm or wrist fractures at 84 months: Calcium+Vitamin D vs. Placebo 3.0% vs. 3.0% OR = 1.01 (95% CI 0.90, 1.14) | | | | | | Withdrawals: 6.8%(1240/18176) vs. 7.1%(1291/18106)
US | | | | | | | | Caucasian, African-American, Hispanic, Asian, Native American | | | | | | | | | | Withdrawals due to adverse events: Not reported
WHI
Kanaji A et al., 2006 ^31^ | Setting: Single center, Long Term | Inclusion criteria: Men, leprosy | Placebo daily vs. Risedronate 2.5 mg daily | Calcium, Vitamin D | Run-in: None | | Assessed at baseline, 6 mo, 12 mo: BMD - DEXA-Spine, Vertebral fracture, Radiographic Vertebral Fractures | NR/63–87 | NR/NR/23 | 2/NR/21 | Number of people with fracture: vertebral fractures at 12 months: Risedronate vs. Placebo 0.8% vs. 1.9% OR = NC | | | | | | Monitored | Placebo vs. Risedronate:
Risedronate | Jadad: 4 | Exclusion criteria: any medication that may alter bone and mineral metabolism | Duration: 8 months | | Wash-out: None | | | 100% male | | | | | | | | | | Withdrawals: 0.0%(0/11) vs. 16.7%(2/12)
Japan | | | | | | | | Asian | | | | | | | | | | Withdrawals due to adverse events: 0.0%(0/11) vs. 0.0%(0/12)
Kananen K et al., 2005 ^32^ | Setting: Single center | Inclusion criteria: Men, Women otherwise undefined, Organ transplant | Control vs. Pamidronate 60 mg variable frequency | Calcium, Estrogen, Testosterone, Vitamin D | Run-in: None | | Assessed at baseline, 1 mo, 3 mo, 6 mo, 12 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Vertebral fracture, Radiographic Vertebral Fractures | 43/NR | 115/108/99 | 33/0/72 | Number of people with fracture: vertebral fractures at 12 months: Pamidronate vs. Control 8.6% vs. 13.2% OR = 0.57 (95% CI 0.13, 2.48) | | | | | | NR | Estrogen, Calcium, Vitamin D vs. Pamidronate:
Estrogen, Pamidronate, Testosterone | Jadad: 1 | Exclusion criteria: Renal insufficiency, Myeloma | Duration: 12 months | | Wash-out: None | | | 50% male | | | | | | | | | | Withdrawals: 32.7%(16/49) vs. 34.0%(17/50)
Finland | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: 30.6%(15/49) vs. 30.0%(15/50)
Kaufman JM et al., 2005 ^33^ | Setting: Multi-center, Community | Inclusion criteria: Men, Osteoporosis T-score <= -2 hip, Osteoporosis T-score <= -2 spine | Placebo daily vs. PTH 20 ug daily vs. PTH 40 ug daily | Calcium, Vitamin D | Run-in: 1 mo of Calcium, 1 mo of Vitamin D | | Assessed at baseline, 3 mo, 6 mo, 12 mo, 18 mo, 30 mo, 42 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Vertebral fracture, Radiographic Vertebral Fractures | 59/30–85 | 959/437/355 | NR/NR/279 | Number of people with fracture: moderate or severe fractures at 30 months: Teriparatide 20 ug vs. Placebo 1.0% vs. 7.0% OR = 0.24 (95% CI 0.06, 0.97) - NNT=17.5 (95% CI 9.1–245.7) Teriparatide 20 ug vs. Teriparatide 40 ug 1.0% vs. 1.0% OR = 1.09 (95% CI 0.07, 17.56) Teriparatide 40 ug vs. Placebo 1.0% vs. 7.0% OR = 0.26 (95% CI 0.06, 1.06) Teriparatide combined vs. Placebo 1.0% vs. 7.0% OR = 0.16 (95% CI 0.04, 0.65) - NNT=17.7 (95% CI 9.3–180.7) | Number of people with fracture: vertebral fractures at 30 months: Teriparatide 20 ug vs. Placebo 5.0% vs. 12.0% OR = 0.46 (95% CI 0.17, 1.24) Teriparatide 20 ug vs. Teriparatide 40 ug 5.0% vs. 6.0% OR = 0.91 (95% CI 0.25, 3.25) Teriparatide 40 ug vs. Placebo 6.0% vs. 12.0% OR = 0.50 (95% CI 0.19, 1.37) Teriparatide combined vs. Placebo 6.0% vs. 12.0% OR = 0.44 (95% CI 0.18, 1.09) | | | | | Reported by patient | Placebo vs. Teriparitide 20ug vs. Teriparitide 40ug: | | NO ADDITIONAL INFORMATION ABOUT ADHERENCE. THIS WAS A FOLLOW-UP STUDY. 1 COUNTRY WAS NOT REPORTED. THIS STUDY WAS DISCONTINUED EARLY SUBJECTS IN ANALYSIS VOLUNTEERED TO FOLLOW-UP.
PTH | Jadad: 4 | Exclusion criteria: Age > 85, Carcinoma or suspected carcinoma, Hyperparathyroidism, Hypoparathyroidism, Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Sprue, Inflammatory bowel disease, Malabsorption syndrome, Nephrolithiasis, Urolithiasis, Anticonvulsants, Aluminum, Bisphosphonates, Calcitonin, Calcium (includes antacids), Coumarins, Fluoride, Androgen, Estrogen agonists (including estrogen), Progestin, Estrogen antagonists, Anabolic steroids, Vitamin D, Corticoids/Glucocorticoids, Abnormal Urinary Calcium, nonambulatory, any medication that may alter bone and mineral metabolism, treatment with calcitriol analogues, age<30, Secondary Osteoporosis, Alcohol Abuse, LS spine abnormalities prohibiting DEXA, treatment with indandione derivatives, Hypercalcemia, Hypocalcemia, Major systemic Disease, drug abuse, Growth Hormone deficiency, poor intestinal calcium absorption | Duration: 11 median months | | Wash-out: None | | | 100% male | | | | | | | | | | Withdrawals: Not reported
US, Canada, Australia/NZ, Netherlands, Italy, Belgium, France, Spain, Sweden | | | | | | | | Caucasian, other | | | | | | | | | | Withdrawals due to adverse events: Not reported
Kim SH et al., 2004 ^34^ | Setting: Single center | Inclusion criteria: Men, Post-menopausal women NOS, Postmenopausal >18 months | Placebo every 3 months vs. Pamidronate 30 mg every 3 months | Steroids | Run-in: None | | Assessed at baseline, 12 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Vertebral fracture, Total fractures | 49/NR | NR/NR/50 | 0/5/45 | Number of people with fracture: vertebral fractures at 12 months: Pamidronate vs. Control 4.0% vs. 30.0% OR = 0.14 (95% CI 0.03, 0.72) - NNT=3.8 (95% CI 2.1–22.2) | | | | | | NR | Pamidronate vs. Placebo:
Pamidronate | Jadad: 2 | Exclusion criteria: Renal insufficiency, Bisphosphonates, bed rest | Duration: 12 months | | Wash-out: None | | | 51% male | | | | | | | | | | Withdrawals: 0.0%(0/25) vs. 20.0%(5/25)
Asia | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: Not reported
Kishimoto H et al., 2006 ^35^ | Setting: Multi-center | Inclusion criteria: Men, Women otherwise undefined, ambulatory, age >50, <70% YAM(young adult mean) spine or <80% YAM and fracture | Placebo daily and Risedronate 17.5 mg weekly vs. Placebo weekly and Risedronate 2.5 mg daily | Calcium | Run-in: None | | Assessed at baseline, 4 wk, 12 wk, 24 wk, 36 wk, 48 wk: BMD - DEXA-Spine, Vertebral fracture, Radiographic Vertebral Fractures | 67/NR | NR/NR/496 | 63/1/488 | Number of people with fracture: vertebral fractures at 48 weeks: Risedronate 17.5 mg/wk+Calcium 200 mg/day vs. Risedronate 2.5 mg/day+Calcium 200 mg/day 2.2% vs. 2.7% OR = 0.81 (95% CI 0.25, 2.68) | | | | | | Monitored, reported by patient | Risedronate 17.5 mg/week vs. Risedronate 2.5 mg/d:
Risedronate | Jadad: 3 | Exclusion criteria: Carcinoma or suspected carcinoma, Cardiovascular disease, Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Gastrointestinal disease, Bisphosphonates, any medication that may alter bone and mineral metabolism, Drug Hypersensitivity, radiation therapy to lumbar spine or pelvis, LS spine abnormalities prohibiting DEXA | Duration: 11 months | | Wash-out: None | | | 3% male | | | | | | | | | | Withdrawals: 9.2%(23/249) vs. 16.2%(40/247)
Japan | | | | | | | | Asian | | | | | | | | | | Withdrawals due to adverse events: 5.2%(13/249) vs. 10.1%(25/247)
Kushida K et al., 2004 ^36^ | Setting: Multi-center | Inclusion criteria: Men, Women otherwise undefined, Osteoporosis NOS, age >50, 1–4 vertebral fractures | Placebo daily for 2 weeks every 12 weeks and Risedronate 2.5 mg daily vs. Placebo daily and Etidronate 200 mg daily for 2 weeks every 12 weeks | Calcium | Run-in: None | | Assessed at baseline, 24 wk, 48 wk, 72 wk, 96 wk: Vertebral fracture | 72/NR | NR/NR/547 | 157/17/433 | Number of people with fracture: vertebral fractures at 24 weeks: Etidronate vs. Risedronate 6.0% vs. 8.8% OR = 0.66 (95% CI 0.32, 1.36) | | | | | | Monitored, reported by patient | Etidronate vs. Risedronate:
Etidronate, Risedronate | Jadad: 4 | Exclusion criteria: Cardiovascular disease, Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Gastrointestinal disease, treatment with Risedronate or Etidronate, Secondary Osteoporosis, radiographic findings that affect vertebral intensity, Med known to affect skeleton, malignancy under treatment with anti-tumor agents, radiation therapy to lumbar spine or pelvis | Duration: 22 months | | Wash-out: None | | | 4% male | | | | | | | | | | Withdrawals: 30.7%(84/274) vs. 26.7%(73/273)
Japan | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: 21.2%(58/274) vs. 13.9%(38/273)
RESIDRONATE PHASE III RESEARCH III RESEARCH GROUP
Luckey M et al., 2004 ^37^ | Setting: Multi-center | Inclusion criteria: Osteoporosis T-score <= -2 hip, Osteoporosis T-score <= -2 spine, Postmenopausal >18 months, Age >40, Age>25 if surgical menopause, Good health | Alendronate 70 mg weekly vs. Raloxifene 60 mg daily | Calcium, Vitamin D | Run-in: None | | Assessed at baseline, 6 mo, 12 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Hip fracture, Proximal humerus fracture, Radial fracture, Vertebral fracture, Total fractures | 64/NR | 1200/508/456 | 76/8/405 | Number of people with fracture: all clinical fractures at 12 months: Alendronate vs. Raloxifene 2.3% vs. 3.5% OR = 0.65 (95% CI 0.22, 1.95) | | | | | | Elicited by investigator, reported by patient | Alendronate vs. Raloxifene:
Alendronate, Raloxifene | Jadad: 5 | Exclusion criteria: Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Upper GI, Venous thromboembolic disease - Active, Venous thromboembolic disease - Ever, Bisphosphonates, Fluoride, Estrogen agonists (including estrogen), SERMS, Anabolic steroids, Corticoids/Glucocorticoids, LS spine abnormalities prohibiting DEXA, Immunosuppressants, Hypocalcemia, previous PTH use, Med known to affect skeleton, Breast Cancer, Uterine Cancer | Duration: 12 months | | Wash-out: None | | | 0% male | | | | | | | | | | Withdrawals: 19.7%(44/223) vs. 17.2%(40/233)
US | | | | | | | | Caucasian, African-American, Asian, other | | | | | | | | | | Withdrawals due to adverse events: 11.2%(25/223) vs. 10.3%(24/233)
THE EFFECT STUDY
McClung MR et al., 2006 ^38^ | Setting: Multi-center | Inclusion criteria: Post-menopausal women NOS, T score lumbar spine -1.8 to -4.0 or hip -1.8 to -3.5 | Placebo vs. AMG 162 6 mg every 3 months vs. AMG 162 14 mg every 3 months vs. AMG 162 30 mg every 3 months vs. AMG 162 14 mg every 6 months vs. AMG 162 60 mg every 6 months vs. AMG 162 100 mg every 6 months vs. AMG 162 210 mg every 6 months vs. Alendronate 70 mg weekly | Calcium, Vitamin D | Run-in: None | | Assessed at baseline, 1 mo, 2 mo, 3 mo, 4 mo, 5 mo, 6 mo, 7 mo, 8 mo, 9 mo, 10 mo, 11 mo, 12 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Proximal humerus fracture, Radial fracture, Vertebral fracture, Total fractures, Symptomatic Vertebral Fractures | 63/NR | NR/NR/412 | 43/NR/268 | Number of people with fracture: clinical vertebral fractures at 12 months: Alendronate vs. Placebo 2.0% vs. 2.0% OR = 1.00 (95% CI 0.06, 16.23) Denosumab vs. Alendronate 4.0% vs. 2.0% OR = 1.60 (95% CI 0.31, 8.40) Denosumab vs. Placebo 4.0% vs. 2.0% OR = 1.60 (95% CI 0.31, 8.40) | Number of people with fracture: humerus fractures at 12 months: Alendronate vs. Placebo 0.0% vs. 0.0% OR = NC Denosumab vs. Alendronate 0.3% vs. 0.0% OR = 3.15 (95% CI 0.01, 1116) Denosumab vs. Placebo 0.3% vs. 0.0% OR = 3.15 (95% CI 0.01, 1116) | Number of people with fracture: radius, ulna, or both at 12 months: Alendronate vs. Placebo 0.0% vs. 0.0% OR = NC Denosumab vs. Alendronate 1.0% vs. 0.0% OR = 3.17 (95% CI 0.11, 94.82) Denosumab vs. Placebo 1.0% vs. 0.0% OR = 3.17 (95% CI 0.11, 94.82) | Number of people with fracture: tarsus, metatarsus, or both at 12 months: Alendronate vs. Placebo 2.0% vs. 2.0% OR = 1.00 (95% CI 0.06, 16.23) Denosumab vs. Alendronate 1.0% vs. 2.0% OR = 0.52 (95% CI 0.04, 7.28) Denosumab vs. Placebo 1.0% vs. 2.0% OR = 0.52 (95% CI 0.04, 7.28) | | | Monitored, reported by patient | Alendronate vs. AMG 162 vs. Placebo:
Alendronate, AMG162 | Jadad: 2 | Exclusion criteria: Hypothyroidism, Hyperthyroidism, Hyperparathyroidism, Hypoparathyroidism, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Malabsorption syndrome, Bisphosphonates, Calcitonin, Fluoride, Androgen, Estrogen agonists (including estrogen), SERMS, Estrogen antagonists, Testosterone, Vitamin D, Corticoids/Glucocorticoids, age >= 80, Hypocalcemia, LS spine abnormalities prohibiting DEXA, previous PTH use, Long bone fracture, greater than one vertebral fracture, Osteoporotic fracture within 2yrs | Duration: 12 months | | Wash-out: None | | | 0% male | | | | Number of people with fracture: lumbar vertebra fractures at 12 months: Alendronate vs. Placebo 0.0% vs. 0.0% OR = NC Denosumab vs. Alendronate 0.3% vs. 0.0% OR = 3.15 (95% CI 0.01, 1116) Denosumab vs. Placebo 0.3% vs. 0.0% OR = 3.15 (95% CI 0.01, 1116) | Number of people with fracture: sternum and ribs at 12 months: Alendronate vs. Placebo 0.0% vs. 0.0% OR = NC Denosumab vs. Alendronate 0.3% vs. 0.0% OR = 3.15 (95% CI 0.01, 1116) Denosumab vs. Placebo 0.3% vs. 0.0% OR = 3.15 (95% CI 0.01, 1116) | Number of people with fracture: tibia, fibula, or both at 12 months: Alendronate vs. Placebo 0.0% vs. 0.0% OR = NC Denosumab vs. Alendronate 1.0% vs. 0.0% OR = 3.17 (95% CI 0.11, 94.82) Denosumab vs. Placebo 1.0% vs. 0.0% OR = 3.17 (95% CI 0.11, 94.82) | | | | Withdrawals: Not reported
US | | | | | | | | Caucasian, African-American, Hispanic | | | | | | | | | | Withdrawals due to adverse events: 0.0%(0/46) vs. 2.2%(7/314) vs. 2.2%(1/46)
Milgrom C et al., 2004 ^39^ | Setting: Single center | Inclusion criteria: Men | Placebo variable frequency vs. Risedronate variable dosage variable frequency | | Run-in: None | | Assessed at baseline, 15 wk: Total fractures | NR/18–28 | 473/473/324 | 216/0/324 | Number of people with fracture: all stress fracture at 14 weeks: Risedronate vs. Placebo 14.5% vs. 13.2% OR = 1.12 (95% CI 0.60, 2.10) | Number of people with fracture: femur fractures at 14 weeks: Risedronate vs. Placebo 6.7% vs. 6.3% OR = 1.06 (95% CI 0.44, 2.57) | Number of people with fracture: tibia fracture at 14 weeks: Risedronate vs. Placebo 9.1% vs. 5.7% OR = 1.65 (95% CI 0.72, 3.78) | | | | Elicited by investigator | Placebo vs. Risedronate:
Risedronate | Jadad: 4 | Exclusion criteria: NR | Duration: 3 months | | Wash-out: None | | | 100% male | | | | Number of people with fracture: metatarsus at 14 weeks: Risedronate vs. Placebo 4.8% vs. 2.5% OR = 1.92 (95% CI 0.61, 6.07) | | | | | | Withdrawals: 64.8%(103/159) vs. 68.5%(113/165)
Israel | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: 7.5%(12/159) vs. 15.2%(25/165)
Muscoso E et al., 2004 ^40^ | Setting: Setting not reported | Inclusion criteria: Women otherwise undefined, Osteoporosis NOS | Alendronate 10 mg daily vs. Clodronate 100 mg weekly vs. Risedronate 5 mg daily vs. Raloxifene 60 mg daily | Calcium, Vitamin D | Run-in: None | | Assessed at 12 mo, 24 mo: BMD - DEXA-Spine, Hip fracture, Radial fracture, Vertebral fracture, Symptomatic Vertebral Fractures | 68/NR | NR/NR/2000 | NR/NR/NR | Number of people with fracture: femoral fractures at 12 months: Alendronate vs. Clodronate 0.1% vs. 0.0% OR = 6.05 (95% CI 0.12, 312.4) Alendronate vs. Raloxifene 0.1% vs. 0.0% OR = 3.00 (95% CI 0.00, 2746) Alendronate vs. Risedronate 0.1% vs. 0.0% OR = 3.00 (95% CI 0.00, 2746) Raloxifene vs. Clodronate 0.0% vs. 0.0% OR = NC Risedronate vs. Clodronate 0.0% vs. 0.0% OR = NC Risedronate vs. Raloxifene 0.0% vs. 0.0% OR = NC | Number of people with fracture: radial fractures at 12 months: Alendronate vs. Clodronate 0.1% vs. 0.0% OR = 6.05 (95% CI 0.12, 312.4) Alendronate vs. Raloxifene 0.1% vs. 0.0% OR = 3.00 (95% CI 0.00, 2746) Alendronate vs. Risedronate 0.1% vs. 0.0% OR = 3.00 (95% CI 0.00, 2746) Raloxifene vs. Clodronate 0.0% vs. 0.0% OR = NC Risedronate vs. Clodronate 0.0% vs. 0.0% OR = NC Risedronate vs. Raloxifene 0.0% vs. 0.0% OR = NC | Number of people with fracture: femoral fractures at 24 months: Alendronate vs. Clodronate 0.2% vs. 0.3% OR = 0.80 (95% CI 0.11, 5.75) Alendronate vs. Raloxifene 0.2% vs. 0.0% OR = 3.01 (95% CI 0.02, 373.9) Alendronate vs. Risedronate 0.2% vs. 0.0% OR = 3.01 (95% CI 0.02, 373.9) Raloxifene vs. Clodronate 0.0% vs. 0.3% OR = 0.32 (95% CI 0.00, 26.74) Risedronate vs. Clodronate 0.0% vs. 0.3% OR = 0.32 (95% CI 0.00, 26.74) Risedronate vs. Raloxifene 0.0% vs. 0.0% OR = NC | Number of people with fracture: vertebral fractures at 24 months: Alendronate vs. Clodronate 0.4% vs. 0.4% OR = 1.07 (95% CI 0.24, 4.75) Alendronate vs. Raloxifene 0.4% vs. 0.0% OR = 3.01 (95% CI 0.10, 91.52) Alendronate vs. Risedronate 0.4% vs. 0.0% OR = 3.01 (95% CI 0.10, 91.52) Raloxifene vs. Clodronate 0.0% vs. 0.4% OR = 0.32 (95% CI 0.01, 11.91) Risedronate vs. Clodronate 0.0% vs. 0.4% OR = 0.32 (95% CI 0.01, 11.91) Risedronate vs. Raloxifene 0.0% vs. 0.0% OR = NC | | | NR | Alendronate vs. Clodronate vs. Raloxifene vs. Risedronate:
Alendronate, Raloxifene, Risedronate | Jadad: 1 | Exclusion criteria: NR | Duration: 24 months | | Wash-out: None | | | 0% male | | | | Number of people with fracture: vertebral fractures at 12 months: Alendronate vs. Clodronate 0.2% vs. 0.4% OR = 0.53 (95% CI 0.09, 3.11) Alendronate vs. Raloxifene 0.2% vs. 0.0% OR = 3.01 (95% CI 0.02, 373.9) Alendronate vs. Risedronate 0.2% vs. 0.0% OR = 3.01 (95% CI 0.02, 373.9) Raloxifene vs. Clodronate 0.0% vs. 0.4% OR = 0.32 (95% CI 0.01, 11.91) Risedronate vs. Clodronate 0.0% vs. 0.4% OR = 0.32 (95% CI 0.01, 11.91) Risedronate vs. Raloxifene 0.0% vs. 0.0% OR = NC | Number of people with fracture: radial fractures at 24 months: Alendronate vs. Clodronate 0.0% vs. 0.0% OR = NC Alendronate vs. Raloxifene 0.0% vs. 0.0% OR = NC Alendronate vs. Risedronate 0.0% vs. 0.0% OR = NC Raloxifene vs. Clodronate 0.0% vs. 0.0% OR = NC Risedronate vs. Clodronate 0.0% vs. 0.0% OR = NC Risedronate vs. Raloxifene 0.0% vs. 0.0% OR = NC | | | | | Withdrawals: Not reported
Italy | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: Not reported
Ninkovic M et al., 2002 ^41^ | Setting: Setting not reported | Inclusion criteria: Organ transplant | Control vs. Pamidronate 60 mg daily | Steroids | Run-in: None | | Assessed at baseline, 3 mo, 6 mo, 12 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Proximal humerus fracture, Vertebral fracture, Total fractures, Radiographic Vertebral Fractures, Symptomatic Vertebral Fractures | 51/19–68 | NR/NR/99 | 28/0/NR | Number of people with fracture: nonvertebral fractures at 12 months: Pamidronate vs. Placebo 2.9% vs. 2.4% OR = 1.21 (95% CI 0.07, 19.96) | Number of people with fracture: vertebral fractures at 12 months: Pamidronate vs. Placebo 8.8% vs. 2.4% OR = 3.48 (95% CI 0.47, 25.98) | | | | | NR | Control vs. Pamidronate: | | PAMIDRONATE GIVEN AS ONE TIME ONLY DOSE, THEN PATIENTS FOLLOWED FOR 12 MONTHS
Pamidronate | Jadad: 2 | Exclusion criteria: Renal insufficiency, Bisphosphonates, retransplantation | Duration: 1 day | | Wash-out: None | | | 50% male | | | | | | | | | | Withdrawals: 29.6%(16/54) vs. 26.7%(12/45)
UK | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: 25.9%(14/54) vs. 13.3%(6/45)
Orwoll ES et al., 2003 ^42^ | Setting: Multi-center | Inclusion criteria: Men, Osteopenia T-score <= -2.0 NOS | Placebo daily vs. PTH 20 ug daily vs. PTH 40 ug daily | Calcium, Vitamin D | Run-in: None | | Assessed at baseline, 1 mo, 3 mo, 6 mo, 12 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Total fractures | 59/NR | 959/NR/437 | 81/NR/NR | Number of people with fracture: nonvertebral fractures at 11 months: Teriparatide 20 ug vs. Placebo 1.3% vs. 2.0% OR = 0.65 (95% CI 0.11, 3.79) Teriparatide 20 ug vs. Teriparatide 40 ug 1.3% vs. 0.7% OR = 1.80 (95% CI 0.19, 17.50) Teriparatide 40 ug vs. Placebo 0.7% vs. 2.0% OR = 0.38 (95% CI 0.05, 2.76) | | | | | | Monitored, reported by patient | Placebo vs. Teriparatide 20 mg vs. Teriparatide 40 mg:
PTH | Jadad: 4 | Exclusion criteria: Age > 85, Carcinoma or suspected carcinoma, Hyperparathyroidism, Hypoparathyroidism, Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Sprue, Inflammatory bowel disease, Malabsorption syndrome, Nephrolithiasis, Urolithiasis, Anticonvulsants, Aluminum, Bisphosphonates, Calcitonin, Calcium (includes antacids), Coumarins, Fluoride, Estrogen agonists (including estrogen), Progestin, Estrogen antagonists, Anabolic steroids, Vitamin D, Corticoids/Glucocorticoids, age<30, Med known to affect skeleton, Alcohol Abuse, drug abuse, LS spine abnormalities prohibiting DEXA, Growth Hormone deficiency, treatment with indandione derivatives | Duration: variable | | Wash-out: None | | | 100% male | | | | | | | | | | Withdrawals: 11.6%(17/147) vs. 18.5%(28/151) vs. 25.9%(36/139)
1100101000 | | | | | | | | Caucasian, other | | | | | | | | | | Withdrawals due to adverse events: 4.8%(7/147) vs. 9.3%(14/151) vs. 12.9%(18/139)
Palomba S et al., 2005 ^43^ | Setting: Multi-center | Inclusion criteria: Post-menopausal women NOS, Osteoporosis T-score <= -2.5 spine, Inflammatory bowel disease | Placebo weekly vs. Risedronate 35 mg weekly | Calcium, Vitamin D | Run-in: None | | Assessed at baseline, 12 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Hip fracture, Radial fracture, Vertebral fracture, Total fractures, Radiographic Vertebral Fractures | 52/NR | 279/97/90 | 9/9/1981 | Number of people with fracture: nonvertebral fractures at 12 months: Risedronate vs. Placebo 0.0% vs. 10.0% OR = 0.13 (95% CI 0.02, 0.95) - NNT=10.2 (95% CI 5.3–148.4) | Number of people with fracture: vertebral fractures at 12 months: Risedronate vs. Placebo 13.0% vs. 34.0% OR = 0.30 (95% CI 0.11, 0.84) - NNT=4.6 (95% CI 2.5–25.8) | | | | | Monitored, reported by patient | Placebo vs. Risedronate:
Risedronate | Jadad: 4 | Exclusion criteria: Carcinoma or suspected carcinoma, Endocrine disease, Hyperparathyroidism, Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Bisphosphonates, Calcitonin, Fluoride, HRT, Anabolic steroids, Proton pump inhibitors, Corticoids/Glucocorticoids, Vitamin D deficient, Hypercalcemia, Hypocalcemia, Med known to affect skeleton, hydrochlorothiazide, active rheumatoid arthritis, tobacco abuse, extremes of BMI (either high or low), other medications that could cause GI irritation | Duration: 12 months | | Wash-out: None | | | 0% male | | | | | | | | | | Withdrawals: 8.9%(4/45) vs. 11.1%(5/45)
Italy | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: 0.0%(0/45) vs. 0.0%(0/45)
Porthouse J et al., 2005 ^44^ | Setting: Multi-center, Community | Inclusion criteria: Post-menopausal women NOS, at least one risk factor for osteoporotic fracture | Control and Education vs. Calcium 1000 mg and Vitamin D 800 I.U. daily | | Run-in: None | | Assessed at baseline, 997 mo: Hip fracture, Radial fracture, Total fractures | 77/NR | 11022/7944/3454 | NR/NR/NR | Number of people with fracture: all fractures at 24 months: Calcium+Vitamin D vs. control group (receiving only advice) equally allocated group 4.0% vs. 3.7% OR = 1.09 (95% CI 0.60, 1.96) Calcium+Vitamin D vs. control group (receiving only advice) unequally allocated group 4.8% vs. 5.0% OR = 0.96 (95% CI 0.63, 1.46) | Number of people with fracture: hip and waist fractures at 24 months: Calcium+Vitamin D vs. control group (receiving only advice) equally allocated group 2.0% vs. 1.5% OR = 1.33 (95% CI 0.56, 3.14) Calcium+Vitamin D vs. control group (receiving only advice) unequally allocated group 2.4% vs. 3.2% OR = 0.76 (95% CI 0.44, 1.30) | | | | | NR | Calcium, Vitamin D vs. Control:
Calcium, Vitamin D | Jadad: 2 | Exclusion criteria: Renal insufficiency, Nephrolithiasis, Urolithiasis, Calcium (includes antacids), age < 70, unable to give informed consent, Hypercalcemia, life expectancy <1/2 years | Duration: variable | | Wash-out: None | | | 0% male | | | | Number of people with fracture: hip fractures at 24 months: Calcium+Vitamin D vs. control group (receiving only advice) equally allocated group 0.8% vs. 0.3% OR = 2.35 (95% CI 0.53, 10.36) Calcium+Vitamin D vs. control group (receiving only advice) unequally allocated group 0.4% vs. 1.1% OR = 0.46 (95% CI 0.17, 1.23) | | | | | | Withdrawals: 8.3%(109/1321) vs. 6.6%(131/1993)
UK | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: Not reported
Prince RL et al., 2006 ^45^ | Setting: Setting not reported | Inclusion criteria: Post-menopausal women NOS | Placebo daily vs. Calcium 1200 mg daily | | Run-in: None | | Assessed at baseline, 60 mo: BMD - DEXA-Hip, Radial fracture, Vertebral fracture, Total fractures, Radiographic Vertebral Fractures, Symptomatic Vertebral Fractures | 75/NR | 4312/1510/1460 | 232/NR/1460 | Number of people with fracture: any appendicular site fractures at 60 months: Calcium vs. Placebo 11.4% vs. 12.9% OR = 0.87 (95% CI 0.64, 1.19) | Number of people with fracture: any site fractures at 60 months: Calcium vs. Placebo 15.1% vs. 17.3% OR = 0.85 (95% CI 0.64, 1.12) | Number of people with fracture: proximal femur fractures at 60 months: Calcium vs. Placebo 1.5% vs. 0.8% OR = 1.86 (95% CI 0.71, 4.83) | Number of people with fracture: spine fractures at 60 months: Calcium vs. Placebo 5.2% vs. 5.3% OR = 0.98 (95% CI 0.62, 1.55) | Number of people with fracture: wrist or hand fractures at 60 months: Calcium vs. Placebo 2.9% vs. 2.7% OR = 1.08 (95% CI 0.58, 2.00) | | Monitored, reported by patient | Calcium vs. Placebo:
Calcium | Jadad: 5 | Exclusion criteria: age < 70, participation in another trial, Med known to affect skeleton, Life expectancy <5 years | Duration: 60 months | | Wash-out: None | | | 0% male | | | | Number of people with fracture: lower limb fractures at 60 months: Calcium vs. Placebo 2.5% vs. 4.2% OR = 0.59 (95% CI 0.34, 1.05) | Number of people with fracture: rib or pelvis fractures at 60 months: Calcium vs. Placebo 2.3% vs. 2.3% OR = 1.00 (95% CI 0.51, 1.97) | Number of people with fracture: upper limb fractures at 60 months: Calcium vs. Placebo 4.0% vs. 4.2% OR = 0.95 (95% CI 0.57, 1.59) | | | | Withdrawals: 15.5%(113/730) vs. 16.3%(119/730)
Australia/NZ | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: Not reported
Quandt SA et al., 2005 ^46^ | Setting: Multi-center | Inclusion criteria: Post-menopausal >2 years, T score<= -1.6 at the femoral neck | Alendronate 5 mg and Alendronate 10 mg daily vs. Placebo daily | | Run-in: None | | Assessed at baseline, 6 mo, 12 mo, 18 mo, 24 mo, 30 mo, 36 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Vertebral fracture, Radiographic Vertebral Fractures | 69/55–80 | NR/NR/3737 | NR/NR/NR | Number of people with fracture: clinical vertebral fractures at 54 months: Alendronate vs. Placebo 0.6% vs. 1.6% OR = 0.43 (95% CI 0.23, 0.79) - NNT=108.6 (95% CI 62.9–396.4) | Number of people with fracture: radiographic vertebral fractures at 54 months: Alendronate vs. Placebo 2.7% vs. 4.6% OR = 0.58 (95% CI 0.41, 0.83) - NNT=52.5 (95% CI 31.8–149.6) | | | | | Monitored, elicited by investigator, reported by patient | Alendronate vs. Placebo: | | TABS COUNTED @ EACH VISITS ALENDRONATE GROUP RECEIVED 2 YRS OF 5MG QD THEN 10MG QD FOR VARIABLE PERIOD OF TIME (UP TO 2.5YRS)
Alendronate | Jadad: 4 | Exclusion criteria: Carcinoma or suspected carcinoma, Cardiovascular disease, Hyperparathyroidism, Hypoparathyroidism, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Malabsorption syndrome, Upper GI, Bisphosphonates, Calcitonin, Fluoride, Estrogen agonists (including estrogen), Progestin, Anabolic steroids, Corticoids/Glucocorticoids, BMD femoral neck < -3, noncompliance, history of bilateral hip replacement, nonambulatory, Alcohol Abuse, age <=55, age >= 80, Major systemic Disease, intending to move within four years, any vertebral deformity, recent major upper GI mucosal erosive disease, participation in another trial, unable to give informed consent, change in thyroid hormone dose, unexpected weight loss > 10% of ideal body weight in last 12 months | Duration: 24 months | | Wash-out: None | | | 0% male | | | | | | | | | | Withdrawals: Not reported
US | | | | | | | | Caucasian, other | | | | | | | | | | Withdrawals due to adverse events: Not reported
FIT
Ravn P et al., 1996 ^47^ | Setting: Single center | Inclusion criteria: Post-menopausal >5 years, T-score at forearm <= -1.5, Body weight > 40 kg and not to exceed ideal body weight by >= 40% | Placebo daily vs. Ibandronate 0.25 mg daily vs. Ibandronate 0.5 mg daily vs. Ibandronate 1.0 mg daily vs. Ibandronate 25 mg daily vs. Ibandronate 5.0 mg daily | Calcium | Run-in: None | | Assessed at baseline, 3 mo, 6 mo, 9 mo, 12 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Total fractures | 65/NR | NR/821/180 | 39/2/180 | Number of people with fracture: fractures at 12 months: Ibandronate 0.25 mg vs. Ibandronate 0.5 mg 0.0% vs. 0.0% OR = NC Ibandronate 0.25 mg vs. Ibandronate 1 mg 0.0% vs. 0.0% OR = NC Ibandronate 0.25 mg vs. Ibandronate 2.5 mg 0.0% vs. 0.0% OR = NC Ibandronate 0.25 mg vs. Ibandronate 5 mg 0.0% vs. 0.0% OR = NC Ibandronate 0.25 mg vs. Placebo 0.0% vs. 3.3% OR = 0.14 (95% CI 0.00, 6.82) Ibandronate 0.5 mg vs. Ibandronate 1 mg 0.0% vs. 0.0% OR = NC Ibandronate 0.5 mg vs. Ibandronate 2.5 mg 0.0% vs. 0.0% OR = NC Ibandronate 0.5 mg vs. Ibandronate 5 mg 0.0% vs. 0.0% OR = NC Ibandronate 0.5 mg vs. Placebo 0.0% vs. 3.3% OR = 0.14 (95% CI 0.00, 6.82) Ibandronate 1 mg vs. Ibandronate 2.5 mg 0.0% vs. 0.0% OR = NC Ibandronate 1 mg vs. Ibandronate 5 mg 0.0% vs. 0.0% OR = NC Ibandronate 1 mg vs. Placebo 0.0% vs. 3.3% OR = 0.14 (95% CI 0.00, 6.82) Ibandronate 2.5 mg vs. Ibandronate 5 mg 0.0% vs. 0.0% OR = NC Ibandronate 2.5 mg vs. Placebo 0.0% vs. 3.3% OR = 0.14 (95% CI 0.00, 6.82) Ibandronate 5 mg vs. Placebo 0.0% vs. 3.3% OR = 0.14 (95% CI 0.00, 6.82) | | | | | | Monitored, reported by patient | Ibandronate 0.25mg vs. Ibandronate 0.5mg vs. Ibandronate 1.0mg vs. Ibandronate 2.5mg vs. Ibandronate 5.0mg vs. Placebo:
Ibandronate | Jadad: 3 | Exclusion criteria: Age > 75, Bisphosphonates, Calcitonin, HRT, Diseases, conditions or treatments known to interfere with calcium metabolism | Duration: 12 months | | Wash-out: None | | | 0% male | | | | | | | | | | Withdrawals: 13.3%(4/30) vs. 26.7%(8/30) vs. 13.3%(4/30) vs. 20.0%(6/30) vs. 40.0%(12/30) vs. 16.7%(5/30)
Western Europe | | | | | | | | Caucasian | | | | | | | | | | Withdrawals due to adverse events: 6.7%(2/30) vs. 10.0%(3/30) vs. 3.3%(1/30) vs. 3.3%(1/30) vs. 3.3%(1/30) vs. 13.3%(4/30)
Recker R et al., 2004 ^48^ | Setting: Multi-center | Inclusion criteria: Post-menopausal >5 years, Osteoporosis T-score <= -2 spine, Osteoporosis/Fracture | Placebo every 3 months vs. Ibandronate 0.5 mg every 3 months vs. Ibandronate 1 mg every 3 months | Calcium, Vitamin D | Run-in: None | | Assessed at baseline, 6 mo, 12 mo, 18 mo, 24 mo, 30 mo, 36 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Hip fracture, Vertebral fracture, Total fractures, Radiographic Vertebral Fractures | 67/55–76 | 16632/NR/2862 | 503/29/2860 | Number of people with fracture: vertebral fractures at 36 months: Ibandronate 0.5 mg vs. Ibandronate 1 mg 8.7% vs. 9.2% OR = 0.96 (95% CI 0.69, 1.33) Ibandronate 0.5 mg vs. Placebo 8.7% vs. 10.7% OR = 0.78 (95% CI 0.57, 1.07) Ibandronate 1 mg vs. Placebo 9.2% vs. 10.7% OR = 0.82 (95% CI 0.60, 1.11) | | | | | | Monitored | Ibandronate 0.5 mg vs. Ibandronate 1 mg vs. Placebo:
Ibandronate | Jadad: 3 | Exclusion criteria: Carcinoma or suspected carcinoma, Hypothyroidism, Hyperthyroidism, Hyperparathyroidism, Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Gastrointestinal disease, Bisphosphonates, Calcitonin, Fluoride, HRT, Corticoids/Glucocorticoids, Alcohol Abuse, Med known to affect skeleton, Hypercalcemia, Hypocalcemia, Contraindication to Ca or Vitamin D, Cyclosporine | Duration: 36 months | | Wash-out: None | | | 0% male | | | | | | | | | | Withdrawals: 16.1%(153/950) vs. 19.5%(187/961) vs. 17.2%(163/949)
US, Western Europe | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: 8.1%(77/950) vs. 10.9%(105/961) vs. 7.5%(71/949)
Recker RR et al., 2006 ^49^ | Setting: Multi-center | Inclusion criteria: Post-menopausal >2 years, Osteoporosis T-score <= -2 hip, ambulatory | Placebo and Alendronate 10 mg daily vs. Placebo and Raloxifene 60 mg daily | Calcium, Vitamin D | Run-in: None | | Assessed at baseline, 997 days: BMD - DEXA-Hip, BMD - DEXA-Spine, Hip fracture, Radial fracture, Vertebral fracture, Total fractures, Radiographic Vertebral Fractures | 66/NR | 5531/1840/1423 | 222/28/1412 | Number of people with fracture: hip fractures at 12 months: Alendronate vs. Raloxifene 0.1% vs. 0.3% OR = 0.50 (95% CI 0.05, 4.84) | Number of people with fracture: nonvertebral fractures at 12 months: Alendronate vs. Raloxifene 2.0% vs. 2.1% OR = 0.94 (95% CI 0.44, 1.91) | Number of people with fracture: vertebral or nonvertebral fractures at 12 months: Alendronate vs. Raloxifene 3.1% vs. 2.9% OR = 1.08 (95% CI 0.59, 2.00) | | | | Monitored, elicited by investigator, reported by patient | Alendronate vs. Raloxifene:
Alendronate, Raloxifene | Jadad: 4 | Exclusion criteria: Hypothyroidism, Hyperthyroidism, Hyperparathyroidism, Hypoparathyroidism, Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Upper GI, Venous thromboembolic disease, Bisphosphonates, Calcitonin, Fluoride, Androgen, Estrogen agonists (including estrogen), Progestin, SERMS, Estrogen antagonists, Anabolic steroids, Testosterone, Vitamin D, Corticoids/Glucocorticoids, any medication that may alter bone and mineral metabolism, Breast Cancer, previous PTH use, vaginal bleeding, age <=50, age > 80, T score<-4.0, fracture T4 to L4 | Duration: variable | | Wash-out: None | | | 0% male | | | | Number of people with fracture: vertebral fractures at 12 months: Alendronate vs. Raloxifene 1.1% vs. 0.7% OR = 1.56 (95% CI 0.52, 4.65) | Number of people with fracture: wrist fractures at 12 months: Alendronate vs. Raloxifene 0.8% vs. 1.1% OR = 0.74 (95% CI 0.26, 2.11) | | | | | Withdrawals: 14.2%(102/716) vs. 13.0%(92/707)
US, Canada | | | | | | | | Caucasian | | | | | | | | | | Withdrawals due to adverse events: 6.0%(43/716) vs. 5.2%(37/707)
EVA trial
Reid IR et al., 1994 ^50^ | Setting: Single center | Inclusion criteria: Post-menopausal women NOS, Osteoporosis/Fracture | Pamidronate 150 mg daily vs. Placebo daily | Calcium | Run-in: None | | Assessed at baseline, 1 yr, 2 yr: BMD - DEXA-Hip, BMD - DEXA-Spine, Vertebral fracture, Radiographic Vertebral Fractures | 66/NR | NR/NR/61 | 13/0/48 | Number of people with fracture: vertebral fractures at 24 months: Pamidronate vs. Placebo 26.9% vs. 45.5% OR = 0.45 (95% CI 0.14, 1.46) | | | | | | Monitored | Pamidronate vs. Placebo:
Pamidronate | Jadad: 4 | Exclusion criteria: Hypothyroidism, Hyperthyroidism, Hepatic insufficiency, Renal insufficiency, Anticonvulsants, Bisphosphonates, Calcitonin, Fluoride, HRT, Anabolic steroids, Corticoids/Glucocorticoids, Major systemic Disease, Hypercalcemia, Hypocalcemia | Duration: 24 months | | Wash-out: None | | | 0% male | | | | | | | | | | Withdrawals: 19.2%(5/26) vs. 36.4%(8/22)
Australia/NZ | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: 11.5%(3/26) vs. 22.7%(5/22)
Reid IR et al., 2002 ^51^ | Setting: Multi-center | Inclusion criteria: Post-menopausal >5 years, Osteoporosis T-score <= -2 spine | Zoledronic acid 0.25 mg every 3 months vs. Zoledronic acid 0.5 mg every 3 months vs. Zoledronic acid 1 mg every 3 months vs. Zoledronic acid 2 mg every 6 months vs. Zoledronic acid 4 mg yearly vs. Placebo every 3 months | Calcium | Run-in: None | | Assessed at baseline, 3 mo, 6 mo, 9 mo, 12 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Vertebral fracture | 64/45–80 | NR/NR/351 | 35/NR/351 | Number of people with fracture: nonvertebral fractures at 12 months: Zoledronic acid 0.25 mg vs. Placebo 0.0% vs. 1.7% OR = 0.13 (95% CI 0.00, 6.71) Zoledronic acid 0.25 mg vs. Zoledronic acid 0.5 mg 0.0% vs. 1.7% OR = 0.13 (95% CI 0.00, 6.59) Zoledronic acid 0.25 mg vs. Zoledronic acid 1 mg 0.0% vs. 3.8% OR = 0.12 (95% CI 0.01, 1.89) Zoledronic acid 0.5 mg vs. Placebo 1.7% vs. 1.7% OR = 1.02 (95% CI 0.06, 16.46) Zoledronic acid 0.5 mg vs. Zoledronic acid 1 mg 1.7% vs. 3.8% OR = 0.46 (95% CI 0.05, 4.54) Zoledronic acid 1 mg vs. Placebo 3.8% vs. 1.7% OR = 2.20 (95% CI 0.22, 21.70) Zoledronic acid 2 mg vs. Placebo 1.6% vs. 1.7% OR = 0.97 (95% CI 0.06, 15.65) Zoledronic acid 2 mg vs. Zoledronic acid 0.25 mg 1.6% vs. 0.0% OR = 7.27 (95% CI 0.14, 366.4) Zoledronic acid 2 mg vs. Zoledronic acid 0.5 mg 1.6% vs. 1.7% OR = 0.95 (95% CI 0.06, 15.39) Zoledronic acid 2 mg vs. Zoledronic acid 1 mg 1.6% vs. 3.8% OR = 0.44 (95% CI 0.04, 4.32) Zoledronic acid 4 mg vs. Placebo 1.7% vs. 1.7% OR = 0.98 (95% CI 0.06, 15.91) Zoledronic acid 4 mg vs. Zoledronic acid 0.25 mg 1.7% vs. 0.0% OR = 7.39 (95% CI 0.15, 372.4) Zoledronic acid 4 mg vs. Zoledronic acid 0.5 mg 1.7% vs. 1.7% OR = 0.97 (95% CI 0.06, 15.64) Zoledronic acid 4 mg vs. Zoledronic acid 1 mg 1.7% vs. 3.8% OR = 0.45 (95% CI 0.05, 4.39) Zoledronic acid 4 mg vs. Zoledronic acid 2 mg 1.7% vs. 1.6% OR = 1.02 (95% CI 0.06, 16.45) | Number of people with fracture: vertebral fractures at 12 months: Zoledronic acid 0.25 mg vs. Placebo 0.0% vs. 0.0% OR = NC Zoledronic acid 0.25 mg vs. Zoledronic acid 0.5 mg 0.0% vs. 0.0% OR = NC Zoledronic acid 0.25 mg vs. Zoledronic acid 1 mg 0.0% vs. 0.0% OR = NC Zoledronic acid 0.5 mg vs. Placebo 0.0% vs. 0.0% OR = NC Zoledronic acid 0.5 mg vs. Zoledronic acid 1 mg 0.0% vs. 0.0% OR = NC Zoledronic acid 1 mg vs. Placebo 0.0% vs. 0.0% OR = NC Zoledronic acid 2 mg vs. Placebo 0.0% vs. 0.0% OR = NC Zoledronic acid 2 mg vs. Zoledronic acid 0.25 mg 0.0% vs. 0.0% OR = NC Zoledronic acid 2 mg vs. Zoledronic acid 0.5 mg 0.0% vs. 0.0% OR = NC Zoledronic acid 2 mg vs. Zoledronic acid 1 mg 0.0% vs. 0.0% OR = NC Zoledronic acid 4 mg vs. Placebo 0.0% vs. 0.0% OR = NC Zoledronic acid 4 mg vs. Zoledronic acid 0.25 mg 0.0% vs. 0.0% OR = NC Zoledronic acid 4 mg vs. Zoledronic acid 0.5 mg 0.0% vs. 0.0% OR = NC Zoledronic acid 4 mg vs. Zoledronic acid 1 mg 0.0% vs. 0.0% OR = NC Zoledronic acid 4 mg vs. Zoledronic acid 2 mg 0.0% vs. 0.0% OR = NC | | | | | NR | Placebo vs. Zoledronic acid 1× 4 mg vs. Zoledronic acid 2× 2 mg vs. Zoledronic acid 4× 0.25 mg vs. Zoledronic acid 4× 0.50 mg vs. Zoledronic acid 4× 1 mg:
Zoledronic acid | Jadad: 3 | Exclusion criteria: Carcinoma or suspected carcinoma, Hypothyroidism, Hyperthyroidism, Hyperparathyroidism, Hypoparathyroidism, Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Bisphosphonates, Fluoride, HRT, Estrogen agonists (including estrogen), >1 Fracture, Vitamin D deficient, Med known to affect skeleton | Duration: 12 months | | Wash-out: None | | | 0% male | | | | | | | | | | Withdrawals: Not reported
Western Europe, Australia | | | | | | | | Caucasian, other | | | | | | | | | | Withdrawals due to adverse events: 1.7%(1/59) vs. 3.3%(2/60) vs. 3.3%(2/61) vs. 6.7%(4/60) vs. 3.4%(2/58) vs. 5.7%(3/53)
Reid IR et al., 2004 ^52^ | Setting: Multi-center | Inclusion criteria: Post-menopausal women NOS, T>-2.5, <+2.0, hysterectomy <15 years prior | Placebo vs. Raloxifene 60 mg daily vs. Raloxifene 150 mg daily vs. Estrogen 0.625 mg daily | Calcium | Run-in: None | | Assessed at baseline, 3 mo, 6 mo, 9 mo, 12 mo, 15 mo, 18 mo, 21 mo, 24 mo, 30 mo, 36 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Vertebral fracture, Radiographic Vertebral Fractures | 53/NR | NR/1522/619 | 234/28/619 | Number of people with fracture: vertebral fractures at 36 months: Estrogen vs. Placebo 1.0% vs. 1.1% OR = 0.88 (95% CI 0.05, 14.27) Raloxifene 150 mg vs. Estrogen 1.0% vs. 1.0% OR = 1.00 (95% CI 0.06, 16.10) Raloxifene 150 mg vs. Placebo 1.0% vs. 1.1% OR = 0.88 (95% CI 0.05, 14.27) Raloxifene 60 mg vs. Estrogen 3.3% vs. 1.0% OR = 3.11 (95% CI 0.43, 22.51) Raloxifene 60 mg vs. Placebo 3.3% vs. 1.1% OR = 2.73 (95% CI 0.38, 19.73) Raloxifene 60 mg vs. Raloxifene 150 mg 3.3% vs. 1.0% OR = 3.11 (95% CI 0.43, 22.51) | | | | | | Elicited by investigator | Estrogen vs. Placebo vs. Raloxifene 150mg/d vs. Raloxifene 60mg/d:
Estrogen, Raloxifene | Jadad: 2 | Exclusion criteria: Hepatic insufficiency, Renal insufficiency, Venous thromboembolic disease - Ever, Anticonvulsants, Bisphosphonates, Calcitonin, Fluoride, Androgen, Estrogen agonists (including estrogen), Progestin, Lipid lowering agents, Vitamin D, Corticoids/Glucocorticoids, age <40, Endocrine disease requiring treatment except thyroid, FSH<40, excessive alcohol intake, >60 years, Breast Cancer, Estrogen Dependent CA, Any cancer except skin in last 5 years, Serious postmenopausal symptoms | Duration: 36 months | | Wash-out: None | | | 0% male | | | | | | | | | | Withdrawals: 35.4%(56/158) vs. 40.8%(62/152) vs. 35.0%(55/157) vs. 40.1%(61/152)
US, Canada, Western Europe, Australia/NZ, South Africa | | | | | | | | Caucasian, other | | | | | | | | | | Withdrawals due to adverse events: 15.8%(25/158) vs. 16.4%(25/152) vs. 19.1%(30/157) vs. 19.1%(29/152)
Reid IR et al., 2006 ^53^ | Setting: Single center | Inclusion criteria: Post-menopausal >5 years, Normal Lumbar Dexa Scan | Placebo daily vs. Calcium 1 g daily | | Run-in: None | | Assessed at baseline, 997 NA: BMD - DEXA-Hip, BMD - DEXA-Spine, Hip fracture, Radial fracture, Vertebral fracture, Total fractures, Radiographic Vertebral Fractures | 74/NR | 2421/1780/1471 | 216/153/1471 | Number of people with fracture: distal forearm fractures at 60 months: Calcium vs. Placebo 4.0% vs. 6.0% OR = 0.62 (95% CI 0.39, 1.00) | Number of people with fracture: hip fractures at 60 months: Calcium vs. Placebo 2.3% vs. 0.7% OR = 3.00 (95% CI 1.29, 6.95) - NNT=61.8 (95% CI 35.1–261.3) | Number of people with fracture: symptomatic fractures at 60 months: Calcium vs. Placebo 16.0% vs. 18.0% OR = 0.87 (95% CI 0.67, 1.14) | | | | Reported by patient | Calcium vs. Placebo: | calcium versus placebo;
Calcium | Jadad: 4 | Exclusion criteria: Carcinoma or suspected carcinoma, Hypothyroidism, Hyperthyroidism, Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Bisphosphonates, Calcium (includes antacids), HRT, Anabolic steroids, Corticoids/Glucocorticoids, age <=55, Med known to affect skeleton, Vitamin D deficient | Duration: 60 months | | Wash-out: None | | | 0% male | | | | Number of people with fracture: osteoporotic fractures at 60 months: Calcium vs. Placebo 14.0% vs. 16.0% OR = 0.84 (95% CI 0.63, 1.11) | Number of people with fracture: vertebral fractures at 60 months: Calcium vs. Placebo 4.0% vs. 5.0% OR = 0.70 (95% CI 0.42, 1.14) | | | | | Withdrawals: 45.9%(336/732) vs. 40.1%(296/739)
Australia/NZ | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: 18.2%(133/732) vs. 14.2%(105/739)
Rosen CJ et al., 2005 ^54^ | Setting: Multi-center | Inclusion criteria: Post-menopausal >6 months, Osteopenia T-score <= -2.0 NOS, Spine/Hip anatomy suitable for Dexa | Placebo and Alendronate 70 mg weekly vs. Placebo and Risedronate 35 mg weekly | Calcium, Vitamin D | Run-in: None | | Assessed at baseline, 3 mo, 6 mo, 12 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Total fractures | 65/NR | 1759/NR/1053 | 138/23/945 | Number of people with fracture: fractures at 12 months: Alendronate vs. Risedronate 5.0% vs. 3.8% OR = 1.35 (95% CI 0.75, 2.43) | | | | | | Monitored, elicited by investigator, reported by patient | Alendronate vs. Risedronate:
Alendronate, Risedronate | Jadad: 4 | Exclusion criteria: Metabolic bone disorder other than osteoporosis, Upper GI, Bisphosphonates, Fluoride, HRT, Estrogen agonists (including estrogen), Anabolic steroids, Corticoids/Glucocorticoids, Immunosuppressants, previous PTH use, Inability to remain 30min upright, Vitamin D deficient | Duration: 12 months | | Wash-out: None | | | 0% male | | | | | | | | | | Withdrawals: 15.8%(82/520) vs. 14.8%(79/533)
US | | | | | | | | Caucasian, African-American, Asian, other | | | | | | | | | | Withdrawals due to adverse events: 6.3%(33/520) vs. 6.4%(34/533)
FOSAMAX ACTONEL COMPARISON TRI
Sato S et al., 2003 ^55^ | Setting: Setting not reported | Inclusion criteria: Men, Pre-menopausal women, Post-menopausal women NOS, Connective Tissue Disease, Glucocorticoids >7.5mg for >90days | Control vs. Etidronate 200 mg daily for 14 days every 3 months | Calcium, Vitamin D, Steroids | Run-in: None | | Assessed at baseline, 24 wk, 48 wk, 144 wk: BMD - DEXA-Spine, Vertebral fracture, Radiographic Vertebral Fractures | 45/21–73 | NR/NR/102 | 46/NR/61 | Number of people with fracture: vertebral fractures at 144 weeks: Etidronate+Calcium+Alphacalcidol vs. Calcium+Alphacalcidol 0.0% vs. 6.5% OR = 0.14 (95% CI 0.01, 2.21) | | | | | | NR | Control vs. Etidronate:
Etidronate | Jadad: 1 | Exclusion criteria: Cardiovascular disease, Renal insufficiency, Med known to affect skeleton, LS spine abnormalities prohibiting DEXA | Duration: 33 months | | Wash-out: None | | | 999% male | | | | | | | | | | Withdrawals: 43.1%(22/51) vs. 47.1%(24/51)
Japan | | | | | | | | Asian | | | | | | | | | | Withdrawals due to adverse events: 7.8%(4/51) vs. 3.9%(2/51)
Sato Y et al., 2004 ^56^ | Setting: Setting not reported | Inclusion criteria: Post-menopausal women NOS, recent hip fracture | Placebo daily for 14days, off meds for 9wks, daily for 2wks vs. Etidronate 200 mg daily for 14days, off meds for 9wks, daily for 2wks | | Run-in: None | | Assessed at 13 wk: Total fractures | 75/70–79 | NR/NR/80 | 7/NR/73 | Number of people with fracture: hip fractures at 3 months: Etidronate vs. Placebo 0.0% vs. 0.0% OR = NC | | | | | | Monitored, reported by patient | Etidronate vs. Placebo:
Etidronate | Jadad: 4 | Exclusion criteria: Cardiovascular disease, Hypothyroidism, Hyperthyroidism, Renal insufficiency, Bisphosphonates, Calcitonin, Estrogen agonists (including estrogen), Vitamin D, Corticoids/Glucocorticoids, nonambulatory, Underlying neurologic disorder, Prior calcium use | Duration: 3 months | | Wash-out: None | | | 0% male | | | | | | | | | | Withdrawals: Not reported
Japan | | | | | | | | Asian | | | | | | | | | | Withdrawals due to adverse events: Not reported
Sato Y et al., 2005 ^57^ | Setting: Single center | Inclusion criteria: Men, Age > 65, first stroke >= 3 months prior to study start date, hemiplegia | Placebo daily vs. Risedronate 2.5 mg daily | | Run-in: None | | Assessed at baseline, 6 mo, 12 mo, 18 mo: Hip fracture | 76/NR | 312/287/280 | 9/4/267 | Number of people with fracture: hip fractures at 18 months: Risedronate sodium vs. Placebo 1.0% vs. 7.0% OR = 0.25 (95% CI 0.08, 0.78) - NNT=16.6 (95% CI 9.1–91.2) | | | | | | Monitored, elicited by investigator, reported by patient | Placebo vs. Risedronate: | | NO ADDITIONAL INFORMATION FOR ADHERENCE QS HIP FRACTURE WAS THE PRIMARY OUTCOME
Risedronate | Jadad: 4 | Exclusion criteria: Cardiovascular disease, Hypothyroidism, Hyperthyroidism, Hyperparathyroidism, Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Upper GI, >1 Fracture, Familial Osteoporosis, Use of any drug known to alter bone metabolism for 3 months or longer during the preceding 12 months | Duration: 18 months | | Wash-out: None | | | 100% male | | | | | | | | | | Withdrawals: 5.0%(7/140) vs. 4.3%(6/140)
Japan | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: 1.4%(2/140) vs. 0.7%(1/140)
Sato Y et al., 2005 ^58^ | Setting: Single center | Inclusion criteria: Post-menopausal women NOS, dementia and probable Alzheimer's dementia | Risedronate 2.5 mg daily vs. Placebo daily | Calcium, Vitamin D | Run-in: None | | Assessed at baseline, 4 wk, 8 wk, 12 wk, 16 wk, 20 wk, 24 wk, 28 wk, 32 wk, 36 wk, 40 wk, 44 wk, 48 wk, 52 wk, 56 wk, 60 wk, 64 wk, 68 wk, 72 wk: Hip fracture, Proximal humerus fracture | 78/NR | 658/510/500 | 33/6/500 | Number of people with fracture: hip fractures at 18 months: Risedronate sodium vs. Placebo 2.0% vs. 8.0% OR = 0.29 (95% CI 0.13, 0.66) - NNT=10.9 (95% CI 7.1–23.5) | Number of people with fracture: nonvertebral fractures at 18 months: Risedronate sodium vs. Placebo 3.0% vs. 13.0% OR = 0.29 (95% CI 0.15, 0.57) - NNT=16.4 (95% CI 9.9–48.2) | | | | | Reported by patient | Control vs. Risedronate: | | NONVERTEBRAL FRACTURES MEASURED AS ADVERSE EVENTS
Risedronate | Jadad: 4 | Exclusion criteria: Cardiovascular disease, Hypothyroidism, Hyperthyroidism, Hyperparathyroidism, Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Anticonvulsants, Bisphosphonates, Calcitonin, Calcium (includes antacids), Estrogen agonists (including estrogen), Vitamin D, Corticoids/Glucocorticoids, age < 70, treatment with Vitamin K, Familial Osteoporosis | Duration: 18 months | | Wash-out: None | | | 0% male | | | | | | | | | | Withdrawals: 8.0%(20/250) vs. 7.6%(19/250)
Japan | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: 4.0%(10/250) vs. 4.0%(10/250)
Sato Y et al., 2005 ^59^ | Setting: Single center | Inclusion criteria: Women otherwise undefined, hemiplegia, stroke >2 years | Placebo daily vs. Vitamin D 1000 I.U. daily | | Run-in: None | | Assessed at baseline, 2 yr: Hip fracture | 74/NR | 137/NR/96 | 11/NR/NR | Number of people with fracture: hip fractures at 24 months: Vitamin D vs. Placebo 0.0% vs. 16.7% OR = 0.12 (95% CI 0.02, 0.90) - NNT=6.0 (95% CI 3.2–56.9) | | | | | | Monitored, elicited by investigator | Placebo vs. Vitamin D:
Vitamin D | Jadad: 4 | Exclusion criteria: Cardiovascular disease, Hypothyroidism, Hyperthyroidism, Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Anticonvulsants, Calcium (includes antacids), Vitamin D, dementia, total disability, hospitalization less than 2yrs, history of previous fracture, Drugs affecting Vitamin D Metabolism, Use of any drug known to alter bone metabolism for 3 months or longer during the preceding 12 months | Duration: 24 months | | Wash-out: None | | | 0% male | | | | | | | | | | Withdrawals: 12.5%(6/48) vs. 10.4%(5/48)
Japan | | | | | | | | Asian | | | | | | | | | | Withdrawals due to adverse events: 0.0%(0/48) vs. 0.0%(0/48)
Sato Y et al., 2005 ^60^ | Setting: Single center | Inclusion criteria: Post-menopausal women NOS, acute onset of hemiplegic stroke | Placebo daily vs. Risedronate 2.5 mg daily | | Run-in: None | | Assessed at 6 mo, 12 mo: Hip fracture | 71/NR | NR/NR/374 | 29/8/345 | Number of people with fracture: hip fractures at 12 months: Risedronate vs. Placebo 0.6% vs. 4.0% OR = 0.22 (95% CI 0.05, 0.88) - NNT=28.9 (95% CI 15.1–316.0) | | | | | | Monitored, reported by patient | Placebo vs. Risedronate:
Risedronate | Jadad: 4 | Exclusion criteria: Cardiovascular disease, Hepatic insufficiency, Renal insufficiency, age <65, Med known to affect skeleton, mental condition that would preclude participation, inability to stand, quadraparesis, artificial nutrition | Duration: 12 months | | Wash-out: None | | | 0% male | | | | | | | | | | Withdrawals: 7.5%(14/187) vs. 8.0%(15/187)
Japan | | | | | | | | Asian | | | | | | | | | | Withdrawals due to adverse events: 0.0%(0/187) vs. 0.0%(0/187)
Sato Y et al., 2006 ^61^ | Setting: Single center | Inclusion criteria: Post-menopausal women NOS, Age > 65, Parkinson's | Placebo and Vitamin D 1000 I.U. daily vs. Alendronate 5 mg and Vitamin D 1000 I.U. daily | | Run-in: None | | Assessed at baseline, 997 yr: Hip fracture | 72/65–85 | 558/NR/288 | 19/8/288 | Number of people with fracture: hip fractures at 48 months: Alendronate+Vitamin D2 vs. Placebo+Vitamin D2 3.1% vs. 10.9% OR = 0.30 (95% CI 0.12, 0.78) - NNT=12.8 (95% CI 7.2–59.7) | | | | | | Monitored, elicited by investigator, reported by patient | Alendronate vs. Placebo:
Alendronate | Jadad: 5 | Exclusion criteria: Cardiovascular disease, Hypothyroidism, Hyperthyroidism, Hyperparathyroidism, Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Bisphosphonates, Calcitonin, Calcium (includes antacids), Estrogen agonists (including estrogen), Vitamin D, Corticoids/Glucocorticoids, treatment with Vitamin K, nonvertebral fracture, Stage 5 Parkinson's | Duration: 24 months | | Wash-out: None | | | 0% male | | | | | | | | | | Withdrawals: 9.0%(13/144) vs. 9.7%(14/144)
Japan | | | | | | | | Asian | | | | | | | | | | Withdrawals due to adverse events: 2.8%(4/144) vs. 2.8%(4/144)
Sato Y et al., 2006 ^62^ | Setting: Multi-center | Inclusion criteria: Men, Women otherwise undefined, ALS (amyotrophic lateral sclerosis) | Placebo q.d ×2wks then off 13wks vs. Etidronate 400 mg qd ×2wks then off 13wks | Vitamin D | Run-in: None | | Assessed at baseline, 1 yr, 2 yr: Proximal humerus fracture, Vertebral fracture, Symptomatic Vertebral Fractures | 63/NR | 85/NR/82 | 7/0/82 | Number of people with fracture: ankle fractures at 24 months: Etidronate vs. Placebo 0.0% vs. 2.0% OR = 0.14 (95% CI 0.00, 6.82) | Number of people with fracture: pelvis fractures at 24 months: Etidronate vs. Placebo 0.0% vs. 2.0% OR = 0.14 (95% CI 0.00, 6.82) | Number of people with fracture: rib fractures at 24 months: Etidronate vs. Placebo 0.0% vs. 2.0% OR = 0.14 (95% CI 0.00, 6.82) | | | | Monitored, elicited by investigator, reported by patient | Etidronate vs. Placebo: | note: only those low in vitamin D based on blood tests received vitamin D supplementation
Etidronate | Jadad: 4 | Exclusion criteria: Med known to affect skeleton | Duration: 24 months | | Wash-out: None | | | 57% male | | | | Number of people with fracture: proximal humerus fractures at 24 months: Etidronate vs. Placebo 2.0% vs. 2.0% OR = 1.00 (95% CI 0.06, 16.27) | Number of people with fracture: vertebral fractures at 24 months: Etidronate vs. Placebo 0.0% vs. 7.0% OR = 0.13 (95% CI 0.01, 1.27) | | | | | Withdrawals: 9.8%(4/41) vs. 7.3%(3/41)
Japan | | | | | | | | Asian | | | | | | | | | | Withdrawals due to adverse events: 2.4%(1/41) vs. 0.0%(0/41)
Sorensen OH et al., 2003 ^63^ | Setting: Multi-center | Inclusion criteria: Post-menopausal >5 years, at least 2 vertebral fractures | Placebo daily vs. Risedronate 5 mg daily | Calcium, Vitamin D | Run-in: None | | Assessed at baseline, 6 mo, 12 mo, 18 mo, 24 mo, 36 mo, 48 mo, 60 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Hip fracture, Proximal humerus fracture, Vertebral fracture, Total fractures, Radiographic Vertebral Fractures | 71/NR | 4400/NR/1226 | 1006/NR/NR | Number of people with fracture: humerus fractures at 24 months: Risedronate 5 mg vs. Placebo 2.2% vs. 4.6% OR = 0.48 (95% CI 0.13, 1.81) | Number of people with fracture: nonvertebral fractures at 24 months: Risedronate 5 mg vs. Placebo 5.2% vs. 8.5% OR = 0.59 (95% CI 0.23, 1.54) | | | | | Monitored, reported by patient | Placebo vs. Risedronate: | 1. This is the followup study for ID # 3168; 2. put a footnote in table: *this is the 2 year extension study of #3168 and not all of the 1226 subjects enrolled in the initial study wither chose to participate in the extension or were eligible to participate
Risedronate | Jadad: 2 | Exclusion criteria: Age > 85, Bisphosphonates, Calcitonin, Fluoride, Hormone use, Estrogen agonists (including estrogen), Progestin, Anabolic steroids, Vitamin D, LS spine abnormalities prohibiting DEXA, any medication that may alter bone and mineral metabolism, noncompliance | Duration: 60 months | | Wash-out: None | | | 0% male | | | | Number of people with fracture: vertebral fractures at 24 months: Risedronate 5 mg vs. Placebo 13.8% vs. 28.2% OR = 0.42 (95% CI 0.22, 0.81) - NNT=6.9 (95% CI 4.0–28.1) | | | | | | Withdrawals: 19.2%(25/130) vs. 14.8%(20/135)
UK, Western Europe, Eastern Europe, Australia/NZ | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: 12.3%(16/130) vs. 7.4%(10/135)
VERT
Tauchmanova L et al., 2006 ^64^ | Setting: Single center | Inclusion criteria: Post-menopausal women NOS, Organ transplant | Control vs. Estradiol 2 mg daily and Dihydroprogesterone 10 mg every day for 14 days/month for 12 months vs. Risedronate 35 mg weekly for 12 months vs. Zoledronic acid 4 mg once every 28days every 3 months for 3 months | Calcium, Vitamin D, Steroids, Cyclosporine | Run-in: None | | Assessed at baseline, 3 mo, 6 mo, 12 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Vertebral fracture, Radiographic Vertebral Fractures | 26/NR | NR/NR/60 | 0/0/60 | Number of people with fracture: vertebral fractures at 12 months: HRT vs. Calcium+Vitamin D 6.0% vs. 13.0% OR = 0.49 (95% CI 0.05, 5.10) Risedronate vs. Calcium+Vitamin D 13.0% vs. 13.0% OR = 1.00 (95% CI 0.13, 7.92) Risedronate vs. HRT 13.0% vs. 6.0% OR = 2.05 (95% CI 0.20, 21.36) Risedronate vs. Zoledronic acid 13.0% vs. 20.0% OR = 0.63 (95% CI 0.10, 4.15) Zoledronic acid vs. Calcium+Vitamin D 20.0% vs. 13.0% OR = 1.59 (95% CI 0.24, 10.51) Zoledronic acid vs. HRT 20.0% vs. 6.0% OR = 3.05 (95% CI 0.38, 24.18) | | | | | | Monitored | Calcium, Vitamin D vs. Estradiol + dihydroprogesterone + calcium vs. Estradiol 2 mg & dihydroprogesterone 10 vs. Risedronate, Calcium, Vitamin D vs. Zoledronic acid, Calcium, Vitamin D vs. Zoledronic acid, C:
Estrogen, Risedronate, Zoledronic acid | Jadad: 1 | Exclusion criteria: NR | | | Wash-out: None | | | 0% male | | | | | | | | | | Withdrawals: 0.0%(0/15) vs. 0.0%(0/15) vs. 0.0%(0/15) vs. 0.0%(0/15) vs. 0.0%(0/15) vs. 0.0%(0/15)
Italy | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: 0.0%(0/15) vs. 0.0%(0/15) vs. 0.0%(0/15) vs. 0.0%(0/15) vs. 0.0%(0/15) vs. 0.0%(0/15)
Torres A et al., 2004 ^65^ | Setting: Single center | Inclusion criteria: Men, Pre-menopausal women, Post-menopausal women NOS, Organ transplant, age >20 | Placebo qod vs. Vitamin D 0.5 ug qod | Calcium, Steroids | Run-in: None | | Assessed at baseline, 3 mo, 12 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Total fractures | 49/NR | NR/NR/90 | 11/8/1971 | Number of people with fracture: symptomatic fractures at 12 months: Calcitriol+Calcium vs. Calcium 0.0% vs. 0.0% OR = NC | | | | | | Monitored | Calcium, Vitamin D vs. Placebo, Calcium:
Calcium, Vitamin D | Jadad: 4 | Exclusion criteria: previous parathyroidectomy | Duration: 3 months | | Wash-out: None | | | 78% male | | | | | | | | | | Withdrawals: 0.0%(0/45) vs. 8.9%(4/45)
Spain | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: 0.0%(0/45) vs. 4.4%(2/45)
Toth E et al., 2005 ^66^ | Setting: Single center | Inclusion criteria: Men, Osteoporosis T-score <= -2.5 hip, Osteoporosis T-score <= -2.5 spine | Control vs. Calcitonin 200 I.U. daily every other month | Calcium, Vitamin D | Run-in: None | | Assessed at baseline, 3 mo, 6 mo, 9 mo, 12 mo, 15 mo, 18 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Proximal humerus fracture, Vertebral fracture, Symptomatic Vertebral Fractures, Radiographic Vertebral Fractures | 59/40–76 | 225/75/71 | 0/0/71 | Number of people with fracture: vertebral fractures at 18 months: Calcitonin nasal spray+Vitamin D+Calcium vs. Vitamin D+Calcium 0.0% vs. 10.0% OR = 0.09 (95% CI 0.01, 0.96) - NNT=10.3 (95% CI 5.0–137.0) | | | | | | Elicited by investigator, reported by patient | Calcium, Vitamin D vs. Calcitonin, Calcium, Vitamin D: | | THE INCIDENCE OF VERTEBRAL AND NONVERTEBRAL FRACTURES WAS A SECONDARY OUTCOME
Calcitonin | Jadad: 1 | Exclusion criteria: Carcinoma or suspected carcinoma, Endocrine disease, Hypothyroidism, Hyperthyroidism, Hyperparathyroidism, Hypoparathyroidism, Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Malabsorption syndrome, Upper GI, Anticonvulsants, Bisphosphonates, Anabolic steroids, Vitamin D, Corticoids/Glucocorticoids, treatment with monofluorophosphate, any vertebral deformity, Secondary Osteoporosis, Hypogonadism, any significant lab abnormalities, any medication that may alter bone and mineral metabolism | Duration: 18 months | | Wash-out: None | | | 100% male | | | | | | | | | | Withdrawals: 0.0%(0/31) vs. 0.0%(0/40)
Eastern Europe | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: 0.0%(0/31) vs. 0.0%(0/40)
Trovas GP et al., 2002 ^67^ | Setting: Setting not reported | Inclusion criteria: Men, Osteoporosis T-score <= -2.5 hip, Osteoporosis T-score <= -2.5 spine | Placebo daily vs. Calcitonin 200 I.U. daily | Calcium | Run-in: None | | Assessed at baseline, 3 mo, 6 mo, 9 mo, 12 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Vertebral fracture, Radiographic Vertebral Fractures | 53/27–74 | NR/NR/28 | 0/0/28 | Number of people with fracture: vertebral fractures at 12 months: Nasal salmon calcitonin vs. Placebo 8.0% vs. 18.2% OR = 0.40 (95% CI 0.04, 4.30) | | | | | | Monitored, reported by patient | Calcitonin vs. Placebo:
Calcitonin | Jadad: 4 | Exclusion criteria: Metabolic bone disorder other than osteoporosis, Secondary Osteoporosis | Duration: 12 months | | Wash-out: None | | | 100% male | | | | | | | | | | Withdrawals: 0.0%(0/15) vs. 0.0%(0/13)
Greece | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: 0.0%(0/15) vs. 0.0%(0/13)
Uchida S et al., 2005 ^68^ | Setting: Multi-center | Inclusion criteria: Men, Post-menopausal >2 years, ambulatory, age 43–90, <70% YAM(young adult mean) spine or <80% YAM and fracture | Alendronate 5 mg daily vs. Alendronate 35 mg weekly | Calcium, Vitamin D | Run-in: None | | Assessed at baseline, 12 wk, 24 wk, 52 wk: BMD - DEXA-Hip, BMD - DEXA-Spine, Total fractures | 67/NR | NR/NR/328 | 51/NR/297 | Number of people with fracture not reported | | | | | | Monitored, reported by patient | Alendronate 35mg / weekly vs. Alendronate 5mg / day:
Alendronate | Jadad: 3 | Exclusion criteria: Bisphosphonates, >1 Fracture | Duration: 12 months | | Wash-out: None | | | 4% male | | | | | | | | | | Withdrawals: 16.1%(27/168) vs. 15.0%(24/160)
Japan | | | | | | | | Asian | | | | | | | | | | Withdrawals due to adverse events: 5.4%(9/168) vs. 8.1%(13/160)
Ushiroyama T et al., 2001 ^69^ | Setting: Single center | Inclusion criteria: Post-menopausal >6 months, Osteopenia, Osteoporosis | Control vs. SQ Calcitonin 10 I.U. every 2 weeks vs. Vitamin D 1 ug daily vs. Vitamin D 1 ug daily and SQ Calcitonin 10 I.U. every 2 weeks | | Run-in: None | | Assessed at baseline, 6 mo, 12 mo, 18 mo, 24 mo: BMD - DEXA-Spine, Vertebral fracture, Total fractures, Symptomatic Vertebral Fractures | 55/53–58 | NR/NR/202 | NR/NR/202 | Number of people with fracture: vertebral fractures at 12 months: 1a-Hydroxycholecalciferol vs. Calcitonin +1a-Hydroxycholecalciferol 0.0% vs. 0.0% OR = NC 1a-Hydroxycholecalciferol vs. No treatment 0.0% vs. 3.8% OR = 0.14 (95% CI 0.01, 2.24) Calcitonin vs. 1a-Hydroxycholecalciferol 0.0% vs. 0.0% OR = NC Calcitonin vs. Calcitonin+1a-Hydroxycholecalciferol 0.0% vs. 0.0% OR = NC Calcitonin vs. No treatment 0.0% vs. 3.8% OR = 0.14 (95% CI 0.01, 2.28) Calcitonin+1a-Hydroxycholecalciferol vs. No treatment 0.0% vs. 3.8% OR = 0.14 (95% CI 0.01, 2.19) | | | | | | Monitored, reported by patient | Vitamin D vs. Calcitonin vs. Calcitonin, Vitamin D vs. Placebo:
Calcitonin | Jadad: 1 | Exclusion criteria: Metabolic bone disorder other than osteoporosis, Renal insufficiency, Urolithiasis, HRT, Estrogen agonists (including estrogen), Contraceptive | Duration: 24 months | | Wash-out: None | | | 0% male | | | | | | | | | | Withdrawals: Not reported
Japan | | | | | | | | Asian | | | | | | | | | | Withdrawals due to adverse events: Not reported
Vogel VG et al., 2006 ^70^ | Setting: Multi-center | Inclusion criteria: Post-menopausal >1 year, hysterectomy bilateral salpingo-oophorectomy, >55 with hysterectomy, <55 with hysterectomy and elevated FSH, 5-yr predicted risk of Breast CA >= 1.66 on Galle Scale | Tamoxifen 20 mg daily vs. Raloxifene 60 mg daily | | Run-in: None | | Assessed at 997 yr: Hip fracture, Radial fracture, Vertebral fracture, Total fractures, Symptomatic Vertebral Fractures | 59/NR | 184460/20168/19747 | NR/1137/19471 | Number of people with fracture: osteoporotic fractures at 60 months: Tamoxifen vs. Raloxifene 1.0% vs. 1.0% OR = 1.09 (95% CI 0.82, 1.44) | | | | | | Monitored, reported by patient | Raloxifene vs. Tamoxifen: | Breast Cancer
Raloxifene, Tamoxifen | Jadad: 3 | Exclusion criteria: Carcinoma or suspected carcinoma, Diabetes, Venous thromboembolic disease - Ever, Coumarins, Androgen, HRT, Estrogen agonists (including estrogen), Progestin, Estrogen antagonists, Contraceptive, age <35, mental condition that would preclude participation, cholestyramine, Uncontrolled HTN, atrial fibrillation, performance status restricting activity | Duration: variable | | Wash-out: None | | | 0% male | | | | | | | | | | Withdrawals: 1.3%(128/9875) vs. 1.5%(146/9872)
US, Canada | | | | | | | | Caucasian, African-American, Hispanic, other | | | | | | | | | | Withdrawals due to adverse events: Not reported
STAR P-2
Wimalawansa SJ, 1998 ^71^ | Setting: Single center | Inclusion criteria: Post-menopausal women NOS, Osteoporosis T-score <= -2 spine, Osteoporosis/Non-traumatic fracture | Control vs. Estrogen 0.625 mg and Norgestrel 150 ug daily vs. Etidronate 400 mg daily for 14 days every 3 months vs. Estrogen 0.625 mg daily, Etidronate 400 mg daily for 14 days every 3 months and Norgestrel 150 ug daily | Calcium, Vitamin D | Run-in: None | | Assessed at baseline, 2 yr, 4 yr: BMD - DEXA-Hip, BMD - DEXA-Spine, Vertebral fracture | 65/58–72 | 350/NR/72 | 13/1/58 | Number of people with fracture: nonvertebral fractures at 48 months: Estrogen+Progesterone vs. Control 6.7% vs. 7.1% OR = 0.93 (95% CI 0.06, 15.69) Etidronate+Estrogen+Progesterone vs. Estrogen+Progesterone 6.7% vs. 6.7% OR = 1.00 (95% CI 0.06, 16.79) Etidronate vs. Control 7.1% vs. 7.1% OR = 1.00 (95% CI 0.06, 16.85) Etidronate vs. Estrogen+Progesterone 7.1% vs. 6.7% OR = 1.07 (95% CI 0.06, 18.10) Etidronate+Estrogen+Progesterone vs. Control 6.7% vs. 7.1% OR = 0.93 (95% CI 0.06, 15.69) Etidronate+Estrogen+Progesterone vs. Etidronate 6.7% vs. 7.1% OR = 0.93 (95% CI 0.06, 15.69) | Number of people with fracture: vertebral fractures at 48 months: Estrogen+Progesterone vs. Control 13.3% vs. 35.7% OR = 0.31 (95% CI 0.06, 1.64) Etidronate+Estrogen+Progesterone vs. Estrogen+Progesterone 6.7% vs. 13.3% OR = 0.49 (95% CI 0.05, 5.10) Etidronate vs. Control 21.4% vs. 35.7% OR = 0.51 (95% CI 0.10, 2.55) Etidronate vs. Estrogen+Progesterone 21.4% vs. 13.3% OR = 1.73 (95% CI 0.26, 11.50) Etidronate+Estrogen+Progesterone vs. Control 6.7% vs. 35.7% OR = 0.18 (95% CI 0.03, 1.06) Etidronate+Estrogen+Progesterone vs. Etidronate 6.7% vs. 21.4% OR = 0.30 (95% CI 0.04, 2.40) | | | | | Monitored | Control vs. Etidronate vs. Estrogen vs. Estrogen, Etidronate: | | INTERVENTIONS - NUMBER COMPLETING/ ANALYZED IS FOR 4 YEAR DATA (2 YEAR DIFFERENT)
Estrogen, Etidronate | Jadad: 3 | Exclusion criteria: Metabolic bone disorder other than osteoporosis, Bisphosphonates, Calcitonin, Fluoride, HRT, Anabolic steroids, Corticoids/Glucocorticoids, oophorectomy, Med known to affect skeleton | Duration: 48 months | | Wash-out: None | | | 0% male | | | | | | | | | | Withdrawals: 22.2%(4/18) vs. 17.6%(3/17) vs. 16.7%(3/18) vs. 21.1%(4/19)
UK | | | | | | | | Caucasian | | | | | | | | | | Withdrawals due to adverse events: 16.7%(3/18) vs. 17.6%(3/17) vs. 16.7%(3/18) vs. 21.1%(4/19)
Zein CO et al., 2005 ^72^ | Setting: Single center | Inclusion criteria: Men, Pre-menopausal women, Post-menopausal women NOS, Primary Biliary Cirrhosis, T <-1.5 of lumbar spine, estimated survival based on Mayo Risk score of >80% at 2 years | Placebo weekly vs. Alendronate 70 mg weekly | Calcium, Vitamin D | Run-in: None | | Assessed at baseline, 6 mo, 12 mo: BMD - DEXA-Hip, BMD - DEXA-Spine, Hip fracture, Vertebral fracture, Radiographic Vertebral Fractures | 61/NR | NR/NR/34 | 6/1/2027 | Number of people with fracture: new compression/vertebral fractures at 12 months: Alendronate vs. Placebo 7.0% vs. 0.0% OR = 6.88 (95% CI 0.14, 347.7) | Number of people with fracture: peripheral fractures at 12 months: Alendronate vs. Placebo 0.0% vs. 7.0% OR = 0.13 (95% CI 0.00, 6.33) | | | | | Monitored, elicited by investigator, reported by patient | Alendronate vs. Placebo:
Alendronate | Jadad: 5 | Exclusion criteria: Hypothyroidism, Hyperthyroidism, Hyperparathyroidism, Renal insufficiency, Upper GI, Anticonvulsants, Calcitonin, Fluoride, Testosterone, Vitamin D, Corticoids/Glucocorticoids, heparin, Med known to affect skeleton, Vitamin D deficient, age >=70, age <18, starting estrogen within one year or discontinuing estrogen in the past | Duration: 12 months | | Wash-out: None | | | 6% male | | | | | | | | | | Withdrawals: 11.8%(2/17) vs. 23.5%(4/17)
US | | | | | | | | Not Reported | | | | | | | | | | Withdrawals due to adverse events: 5.9%(1/17) vs. 11.8%(2/17)

### Reference List for Evidence Table C2

1 Agrawal S, Krueger DC, Engelke JA, et al. (2006). Between-meal risedronate does not alter bone turnover in nursing home residents. J Am Geriatr Soc.
2 Aris RM, Lester GE, Renner JB, et al. (2000). Efficacy of pamidronate for osteoporosis in patients with cystic fibrosis following lung transplantation. American journal of respiratory and critical care medicine.
3 Black DM, Delmas PD, Eastell R, et al. (2007). Once-yearly zoledronic acid for treatment of postmenopausal osteoporosis. N Engl J Med.
4 Body JJ, Gaich GA, Scheele WH, et al. (2002). A randomized double-blind trial to compare the efficacy of teriparatide. J Clin Endocrinol Metab.
5 Bone HG, Greenspan SL, McKeever C, et al. (2000). Alendronate and estrogen effects in postmenopausal women with low bone mineral density. Alendronate/Estrogen Study Group. J Clin Endocrinol Metab.
6 Bonnick S, Saag KG, Kiel DP, et al. Comparison of Weekly Treatment of Postmenopausal Osteoporosis with Alendronate versus Risedronate Over Two Years. J Clin Endocrinol Metab 2006.
7 Boutsen Y, Jamart J, Esselinckx W, et al. (1997). Primary prevention of glucocorticoid-induced osteoporosis with intermittent intravenous pamidronate: a randomized trial. Calcif Tissue Int.
8 Brown JP, Kendler DL, McClung MR, et al. (2002). The efficacy and tolerability of risedronate once a week for the treatment of postmenopausal osteoporosis. Calcif Tissue Int.
9 Campbell IA, Douglas JG, Francis RM, et al. (2004). Five year study of etidronate and/or calcium as prevention and treatment for osteoporosis and fractures in patients with asthma receiving long term oral and/or inhaled glucocorticoids. Thorax.
10 Chapurlat RD, Palermo L, Ramsay P, et al. (2005). Risk of fracture among women who lose bone density during treatment with alendronate. The Fracture Intervention Trial. Osteoporos Int.
11 Chesnut CH, Skag A, Christiansen C, et al. (2004). Effects of oral ibandronate administered daily or intermittently on fracture risk in postmenopausal osteoporosis. Journal of bone and mineral research : the official journal of the American Society for Bone and Mineral Research.
12 Coco M, Glicklich D, Faugere MC, et al. (2003). Prevention of bone loss in renal transplant recipients: a prospective, randomized trial of intravenous pamidronate. Journal of the American Society of Nephrology : JASN.
13 Fisher B, Costantino JP, Wickerham DL, et al. (1998). Tamoxifen for prevention of breast cancer: report of the National Surgical Adjuvant Breast and Bowel Project P-1 Study. J Natl Cancer Inst.
14 Fukunaga M, Kushida K, Kishimoto H, et al. (2002). A comparison of the effect of risedronate and etidronate on lumbar bone mineral density in Japanese patients with osteoporosis: a randomized controlled trial. Osteoporos Int.
15 Gallagher JC, Genant HK, Crans GG, et al. (2005). Teriparatide reduces the fracture risk associated with increasing number and severity of osteoporotic fractures. The Journal of clinical endocrinology and metabolism.
16 Garcia-Delgado I PSG-FLRERJHF. Calcitonin, etidronate, and calcidiol treatment in bone loss after cardiac transplantation. Calcified tissue international 1997;60(2):155–9.
17 Grant AM, Avenell A, Campbell MK, et al. (2005). Oral vitamin D3 and calcium for secondary prevention of low-trauma fractures in elderly people (Randomised Evaluation of Calcium Or vitamin D, RECORD): a randomised placebo-controlled trial. Lancet.
18 Greenspan SL, Resnick NM, Parker RA. (2003). Combination therapy with hormone replacement and alendronate for prevention of bone loss in elderly women: a randomized controlled trial. JAMA.
19 Greenspan SL, Bhattacharya RK, Sereika SM, et al. Prevention of Bone Loss in Survivors of Breast Cancer: A Randomized, Double-Blind, Placebo-Controlled Clinical Trial. J Clin Endocrinol Metab 2006.
20 Grotz W, Nagel C, Poeschel D, et al. (2001). Effect of ibandronate on bone loss and renal function after kidney transplantation. Journal of the American Society of Nephrology : JASN.
21 Guanabens N PARIALPFCLMAMdOMRMPPRJ. Alendronate is more effective than etidronate for increasing bone mass in osteopenic patients with primary biliary cirrhosis. The American journal of gastroenterology 2003;98(10):2268–74.
22 Harris ST, Watts NB, Li Z, et al. (2004). Two-year efficacy and tolerability of risedronate once a week for the treatment of women with postmenopausal osteoporosis. Curr Med Res Opin.
23 Hay JE, Malinchoc M, Dickson ER. (2001). A controlled trial of calcitonin therapy for the prevention of post-liver transplantation atraumatic fractures in patients with primary biliary cirrhosis and primary sclerosing cholangitis. J Hepatol.
24 Hizmetli S, Elden H, Kaptanoglu E, et al. (1998). The effect of different doses of calcitonin on bone mineral density and fracture risk in postmenopausal osteoporosis. Int J Clin Pract.
25 Hochberg MC, Thompson DE, Black DM, et al. (2005). Effect of alendronate on the age-specific incidence of symptomatic osteoporotic fractures. J Bone Miner Res.
26 Hooper MJ, Ebeling PR, Roberts AP, et al. (2005). Risedronate prevents bone loss in early postmenopausal women: a prospective randomized, placebo-controlled trial. Climacteric.
27 Hosking D, Adami S, Felsenberg D, et al. (2003). Comparison of change in bone resorption and bone mineral density with once-weekly alendronate and daily risedronate: a randomised, placebo-controlled study. Current medical research and opinion.
28 Ishida Y, Kawai S. (2004). Comparative efficacy of hormone replacement therapy, etidronate, calcitonin, alfacalcidol, and vitamin K in postmenopausal women with osteoporosis: The Yamaguchi Osteoporosis Prevention Study. The American Journal of Medicine.
29 Iwamoto J, Takeda T, Ichimura S, et al. (2003). Comparative effects of treatment with etidronate and alendronate on bone resorption, back pain, and activities of daily living in elderly women with vertebral fractures. Keio J Med.
30 Jackson RD, LaCroix AZ, Gass M, et al. (2006). Calcium plus vitamin D supplementation and the risk of fractures. N Engl J Med.
31 Kanaji A, Higashi M, Namisato M, et al. (2006). Effects of risedronate on lumbar bone mineral density, bone resorption, and incidence of vertebral fracture in elderly male patients with leprosy. Lepr Rev.
32 Kananen K, Volin L, Laitinen K, et al. (2005). Prevention of bone loss after allogeneic stem cell transplantation by calcium, vitamin D, and sex hormone replacement with or without pamidronate. J Clin Endocrinol Metab.
33 Kaufman JM, Orwoll E, Goemaere S, et al. (2005). Teriparatide effects on vertebral fractures and bone mineral density in men with osteoporosis: treatment and discontinuation of therapy. Osteoporos Int.
34 Kim SH, Lim SK, Hahn JS. (2004). Effect of pamidronate on new vertebral fractures and bone mineral density in patients with malignant lymphoma receiving chemotherapy. The American journal of medicine.
35 Kishimoto H, Fukunaga M, Kushida K, et al. (2006). Efficacy and tolerability of once-weekly administration of 17.5 mg risedronate in Japanese patients with involutional osteoporosis: a comparison with 2.5-mg once-daily dosage regimen. J Bone Miner Metab.
36 Kushida K, Fukunaga M, Kishimoto H, et al. (2004). A comparison of incidences of vertebral fracture in Japanese patients with involutional osteoporosis treated with risedronate and etidronate: a randomized, double-masked trial. Journal of Bone and Mineral Metabolism.
37 Luckey M, Kagan R, Greenspan S, et al. (2004). Once-weekly alendronate 70 mg and raloxifene 60 mg daily in the treatment of postmenopausal osteoporosis. Menopause.
38 McClung MR, Lewiecki EM, Cohen SB, et al. (2006). Denosumab in postmenopausal women with low bone mineral density. N Engl J Med.
39 Milgrom C, Finestone A, Novack V, et al. (2004). The effect of prophylactic treatment with risedronate on stress fracture incidence among infantry recruits. Bone.
40 Muscoso E, Puglisi N, Mamazza C, et al. (2004). Antiresorption therapy and reduction in fracture susceptibility in the osteoporotic elderly patient: open study. Eur Rev Med Pharmacol Sci.
41 Ninkovic M, Love S, Tom BD, et al. (2002). Lack of effect of intravenous pamidronate on fracture incidence and bone mineral density after orthotopic liver transplantation. J Hepatol.
42 Orwoll ES, Scheele WH, Paul S. (2003). The effects of teriparatide[human parathyroid hormone(1–34)] therapy on bone density in men with osteoporosis. J Bone Miner Res.
43 Palomba S, Orio F, Manguso F, et al. (2005). Efficacy of risedronate administration in osteoporotic postmenopausal women affected by inflammatory bowel disease. Osteoporos Int.
44 Porthouse J, Cockayne S, King C, et al. (2005). Randomised controlled trial of calcium and supplementation with cholecalciferol (vitamin D3) for prevention of fractures in primary care. BMJ.
45 Prince RL, Devine A, Dhaliwal SS, et al. (2006). Effects of calcium supplementation on clinical fracture and bone structure: results of a 5-year, double-blind, placebo-controlled trial in elderly women. Arch Intern Med.
46 Quandt SA, Thompson DE, Schneider DL, et al. (2005). Effect of alendronate on vertebral fracture risk in women with bone mineral density T scores of-1.6 to -2.5 at the femoral neck: the Fracture Intervention Trial. Mayo Clin Proc.
47 Ravn P, Clemmesen B, Riis BJ, et al. (1996). The effect on bone mass and bone markers of different doses of ibandronate: a new bisphosphonate for prevention and treatment of postmenopausal osteoporosis: a 1-year, randomized, double-blind, placebo-controlled dose-finding study. Bone.
48 Recker R, Stakkestad JA, Chesnut CH, et al. (2004). Insufficiently dosed intravenous ibandronate injections are associated with suboptimal antifracture efficacy in postmenopausal osteoporosis. Bone.
49 Recker RR, Kendler D, Recknor CP, et al. Comparative effects of raloxifene and alendronate on fracture outcomes in postmenopausal women with low bone mass. Bone 2006.
50 Reid IR, Wattie DJ, Evans MC, et al. (1994). Continuous therapy with pamidronate, a potent bisphosphonate, in postmenopausal osteoporosis. J Clin Endocrinol Metab.
51 Reid IR, Brown JP, Burckhardt P, et al. (2002). Intravenous zoledronic acid in postmenopausal women with low bone mineral density. N Engl J Med.
52 Reid IR, Eastell R, Fogelman I, et al. (2004). A comparison of the effects of raloxifene and conjugated equine estrogen on bone and lipids in healthy postmenopausal women. Arch Intern Med.
53 Reid IR, Mason B, Horne A, et al. (2006). Randomized controlled trial of calcium in healthy older women. Am J Med.
54 Rosen CJ, Hochberg MC, Bonnick SL, et al. (2005). Treatment with once-weekly alendronate 70 mg compared with once-weekly risedronate 35 mg in women with postmenopausal osteoporosis: a randomized double-blind study. J Bone Miner Res.
55 Sato S, Ohosone Y, Suwa A, et al. (2003). Effect of intermittent cyclical etidronate therapy on corticosteroid induced osteoporosis in Japanese patients with connective tissue disease: 3 year followup. J Rheumatol.
56 Sato Y, Kanoko T, Yasuda H, et al. (2004). Beneficial effect of etidronate therapy in immobilized hip fracture patients. Am J Phys Med Rehabil.
57 Sato Y, Iwamoto J, Kanoko T, et al. (2005). Risedronate sodium therapy for prevention of hip fracture in men 65 years or older after stroke. Arch Intern Med.
58 Sato Y, Kanoko T, Satoh K, et al. (2005). The prevention of hip fracture with risedronate and ergocalciferol plus calcium supplementation in elderly women with Alzheimer disease: a randomized controlled trial. Arch Intern Med.
59 Sato Y IJKTSK. Low-dose vitamin D prevents muscular atrophy and reduces falls and hip fractures in women after stroke: a randomized controlled trial. Cerebrovasc Dis 2005;20(3):187–92.
60 Sato Y, Iwamoto J, Kanoko T, et al. (2005). Risedronate therapy for prevention of hip fracture after stroke in elderly women. Neurology.
61 Sato Y, Iwamoto J, Kanoko T, et al. Alendronate and vitamin D2 for prevention of hip fracture in Parkinson's disease: A randomized controlled trial. Mov Disord 2006.
62 Sato Y, Honda Y, Iwamoto J. Etidronate for fracture prevention in amyotrophic lateral sclerosis: A randomized controlled trial. Bone 2006.
63 Sorensen OH, Crawford GM, Mulder H, et al. (2003). Long-term efficacy of risedronate: a 5-year placebo-controlled clinical experience. Bone.
64 Tauchmanova L, De Simone G, Musella T, et al. (2006). Effects of various antireabsorptive treatments on bone mineral density in hypogonadal young women after allogeneic stem cell transplantation. Bone Marrow Transplant.
65 Torres A, Garcia S, Gomez A, et al. (2004). Treatment with intermittent calcitriol and calcium reduces bone loss after renal transplantation. Kidney Int.
66 Toth E, Csupor E, Meszaros S, et al. (2005). The effect of intranasal salmon calcitonin therapy on bone mineral density in idiopathic male osteoporosis without vertebral fractures—an open label study. Bone.
67 Trovas GP, Lyritis GP, Galanos A, et al. (2002). A randomized trial of nasal spray salmon calcitonin in men with idiopathic osteoporosis: effects on bone mineral density and bone markers. J Bone Miner Res.
68 Uchida S, Taniguchi T, Shimizu T, et al. (2005). Therapeutic effects of alendronate 35 mg once weekly and 5 mg once daily in Japanese patients with osteoporosis: a double-blind, randomized study. J Bone Miner Metab.
69 Ushiroyama T, Ikeda A, Sakai M, et al. (2001). Effects of the combined use of calcitonin and 1 alpha-hydroxycholecalciferol on vertebral bone loss and bone turnover in women with postmenopausal osteopenia and osteoporosis: a prospective study of long-term and continuous administration with low dose calcitonin. Maturitas.
70 Vogel VG, Costantino JP, Wickerham DL, et al. (2006). Effects of tamoxifen vs raloxifene on the risk of developing invasive breast cancer and other disease outcomes: the NSABP Study of Tamoxifen and Raloxifene (STAR) P-2 trial. Jama.
71 Wimalawansa SJ. (1998). A four-year randomized controlled trial of hormone replacement and bisphosphonate, alone or in combination, in women with postmenopausal osteoporosis. Am J Med.
72 Zein CO, Jorgensen RA, Clarke B, et al. (2005). Alendronate improves bone mineral density in primary biliary cirrhosis: a randomized placebo-controlled trial. Hepatology.

## Evidence Table C3. Quality Tables for Randomized Controlled Trials

Evidence Table C3. Quality Tables for Randomized Controlled Trials

Author, Year, Drug, Country, Trial name | Randomization adequate? | Allocation concealment adequate? | Groups similar at baseline? | Eligibility criteria specified? | Outcomes assessors masked? | Care provider masked? | Patient masked? | Reporting of adherence and contamination? | Loss to follow-up: differential/high? | Intention-to-treat (ITT) analysis? | Quality rating (Jadad score) | Number screened/eligible/enrolled | Exclusion criteria | Run-in/Washout | Class naive patients only? | Control group standard of care? | Funding | Relevance?
Agrawal S et al., 2006 ^1^ | Not described | Not described | Yes | Yes | NR | Yes | Yes | Yes/Yes | No | No | 4 | 64/NR/60 | Carcinoma or suspected carcinoma, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Med known to affect skeleton, age <65, any significant lab abnormalities, Osteoporotic fracture within 2yrs | NR | Not reported | Yes | Source: Industry; Role: described | Limited
Risedronate | | | | | | | | | | | | | | NR
US
Aris RM et al., 2000 ^2^ | Yes | Not described | Yes | Yes | Yes | No | No | NR/NR | No | Yes | 3 | 44/37/37 | Pregnancy, Renal insufficiency, Life expectancy <5 years, Graft Failure | NR | Not reported | Yes | Source: Government & Private; Role: NR | Limited
Pamidronate | | | | | | | | | | | | | | NR
US
Black DM et al., 2007 ^3^ | Yes | Not described | Yes | Yes | Yes | NR | Yes, but not described | Yes/NR | NR | Yes | 4 | 18421/9977/7765 | Bisphosphonates, Fluoride, Anabolic steroids, Corticoids/Glucocorticoids, Hypercalcemia, Hypocalcemia, previous PTH use, >2+ protein on urine dipstick, bisphosphonate use for >=48 weeks within 2 years prior to study, Growth Hormone use, strontium use, calculated creatinine clearance, 30.0 ml/min | NR | No | Yes | Source: Industry; Role: described | Yes
Zoledronic acid | | | | | | | | | | | | | | NR
US, Canada, Latin Amer, Western Europe, Eastern Europe, Australia/NZ, Asia
Horizon
Body JJ et al., 2002 ^4^ | Not described | Not described | Yes | Yes | Yes, but not described | Yes, but not described | Yes, but not described | Yes/NR | No | Yes | 4 | 265/149/149 | Age > 85, Carcinoma or suspected carcinoma, Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Malabsorption syndrome, Urolithiasis, Bisphosphonates, Calcitonin, Fluoride, Androgen, Estrogen agonists (including estrogen), Anabolic steroids, Corticoids/Glucocorticoids, Alcohol Abuse, Allergy to PTH, age<30, LS spine abnormalities prohibiting DEXA, previous PTH use | Run-in period reported | Yes | Yes | Source: Industry; Role: NR | Yes
Alendronate, PTH | | | | | | | | | | | | | | NR
US, Canada, Latin America, Western Europe, Israel
Bone HG et al., 2000 ^5^ | Yes | Not described | Yes | Yes | NR | Yes, but not described | Yes, but not described | NR/NR | No | Yes | 4 | NR/NR/425 | Cardiovascular disease, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Venous thromboembolic disease - Active, Venous thromboembolic disease - Ever, Bisphosphonates, Calcitonin, Fluoride, Vitamin D deficient, recent major upper GI mucosal erosive disease, Increased risk of breast cancer, Unexplained genital bleeding × 1 year, Fasting triglycerides >400mg/dL, Contraindication to HRT, HRT within last 6 months | NR | Not reported | No | Source: Industry; Role: NR | Yes
Alendronate, Estrogen | | | | | | | | | | | | | | NR
US
ALENDRONATE ESTROGEN STUDY GRP
Bonnick S et al., 2006 ^6^ | Yes | Not described | Yes | Yes | Yes | Yes | Yes | NR/NR | NR | Yes | 4 | 1759/NR/1053 | Metabolic bone disorder other than osteoporosis, Upper GI, Bisphosphonates, Fluoride, HRT, Estrogen agonists (including estrogen), Anabolic steroids, Corticoids/Glucocorticoids, Vitamin D deficient, previous PTH use, Hypocalcemia, Immunosuppressants | NR | Not reported | Yes | Source: Industry; Role: NR | Yes
Alendronate, Risedronate | | | | | | | | | | | | | | NR
US
FACT
Boutsen Y et al., 1997 ^7^ | Yes | Not described | Yes | Yes | NR | NR | NR | NR/NR | No | No | 3 | NR/NR/32 | Carcinoma or suspected carcinoma, Hypothyroidism, Hyperthyroidism, Hyperparathyroidism, Hepatic insufficiency, Renal insufficiency, Urolithiasis, Bisphosphonates, Fluoride, Previous Glucocorticoids | NR | Yes | No | Source: Not reported | Yes
Pamidronate | | | | | | | | | | | | | | NR
Western Europe
Brown JP et al., 2002 ^8^ | Not described | Not described | Yes | Yes | Yes | Yes | Yes | Yes/NR | NR | Yes | 3 | 4972/NR/1468 | Med known to affect skeleton, LS spine abnormalities prohibiting DEXA | NR | Not reported | Yes | Source: Industry; Role: NR | Yes
Risedronate | | | | | | | | | | | | | | NR
US, Canada
Campbell IA et al., 2004 ^9^ | Yes | No | Yes | Yes | NR | No | No | NR/NR | No | Yes | 2 | NR/NR/352 | Hysterectomy, age <=50, age >=70 | NR | Not reported | No | Source: Industry; Role: NR | Yes
Etidronate | | | | | | | | | | | | | | NR
UK
Chapurlat RD et al., 2005 ^10^ | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes/NR | NR | No | 4 | NR/NR/1746 | Cardiovascular disease, Hypothyroidism, Hyperthyroidism, Hyperparathyroidism, Hepatic insufficiency, Renal insufficiency, Malabsorption syndrome, Upper GI, Bisphosphonates, Calcitonin, Fluoride, Estrogen agonists (including estrogen), age >= 80, age <=55, life expectancy =<3yrs | NR | Yes | Yes | Source: Industry; Role: NR | Yes
[Hip] | | | | | | | | | | | | | | NR
Alendronate
US
FIT
Chapurlat RD et al., 2005 ^10^ | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes/NR | NR | No | 4 | NR/NR/1318 | Cardiovascular disease, Hypothyroidism, Hyperthyroidism, Hyperparathyroidism, Hepatic insufficiency, Renal insufficiency, Malabsorption syndrome, Upper GI, Bisphosphonates, Calcitonin, Fluoride, Estrogen agonists (including estrogen), age >= 80, age <=55, life expectancy =<3yrs | NR | Yes | Yes | Source: Industry; Role: NR | Yes
[Spine] | | | | | | | | | | | | | | NR
Alendronate
US
FIT
Chesnut CH et al., 2004 ^11^ | Yes | Not described | Yes | Yes | NR | Yes | Yes | NR/NR | NR | Yes | 4 | 18447/NR/2946 | Metabolic bone disorder other than osteoporosis, Renal insufficiency, Bisphosphonates, Fluoride, Med known to affect skeleton, Diseases known to affect skeleton, > 2 fractures lumbar spine, Contraindication to Ca or Vitamin D, Hypercalcemia, Hypocalcemia, age <=55, age >= 80, T score<-5.0 | NR | Yes | Yes | Source: Industry; Role: NR | Yes
Ibandronate | | | | | | | | | | | | | | NR
US, Canada, UK, Western Europe, Eastern Europe
BONE
Coco M et al., 2003 ^12^ | Yes | Not described | Yes | Yes | NR | NR | NR | NR/NR | NR | No | 2 | 112/98/72 | Pregnancy | NR | Not reported | Yes | Source: Not reported | Yes
Pamidronate | | | | | | | | | | | | | | NR
US
Cosman F et al., 2001 ^13^ | Yes | Not described | Yes | Yes | Yes | NR | NR | NR/NR | No | No | 3 | 280/174/52 | Metabolic bone disorder other than osteoporosis, Nephrolithiasis | NR | Not reported | Yes | Source: Government; Role: NR | Yes
Estrogen, PTH | | | | | | | | | | | | | | Washout period reported
US
Cosman F et al., 2005 ^14^ | Yes | Not described | Yes | Yes | Yes | No | No | Yes/NR | No | No | 3 | 1345/131/126 | Hypothyroidism, Hyperthyroidism, Hyperparathyroidism, Hypoparathyroidism, Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Nephrolithiasis, Anticonvulsants, Estrogen agonists (including estrogen), Corticoids/Glucocorticoids, Abnormal Urinary Calcium, Abnormal CBC | NR | No | No | Source: Government; Role: described | Yes
Alendronate, PTH | | | | | | | | | | | | | | NR
US
Fisher B et al., 1998 ^15^ | Yes | Yes | NR | Yes | NR | Yes, but not described | Yes, but not described | NR/NR | No | No | 3 | 98018/13954/13388 | Pregnancy, Hepatic insufficiency, Renal insufficiency, Venous thromboembolic disease, Estrogen agonists (including estrogen), Progestin, Contraceptive, Breast Cancer, Abnormal CBC | NR | Not reported | Yes | Source: Government; Role: NR | Yes
Tamoxifen | | | | | | | | | | | | | | NR
US, Canada
NSABP-P1
Fukunaga M et al., 2002 ^16^ | Not described | Not described | Yes | Yes | Yes | Yes | Yes | NR/NR | No | No | 3 | 362/NR/235 | Age > 75, Carcinoma or suspected carcinoma, Cardiovascular disease, Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Upper GI, LS spine abnormalities prohibiting DEXA, Med known to affect skeleton, Drug Hypersensitivity, History of Radiotherapy | NR | Not reported | No | Source: Industry; Role: NR | Yes
Etidronate, Risedronate | | | | | | | | | | | | | | NR
Japan
RESIDRONATE PHASE III RESEARCH
Gallagher JC et al., 2005 ^17^ | Not described | Not described | Yes | Yes | Yes | Yes, but not described | Yes, but not described | NR/NR | NR | No | 2 | 9347/NR/931 | Hepatic insufficiency, Renal insufficiency, Urolithiasis, nonambulatory, Alcohol Abuse, drug abuse, any medication that may alter bone and mineral metabolism, illnesses that affect bone and calcium metabolism | NR | Not reported | Yes | Source: Industry; Role: NR | Yes
PTH | | | | | | | | | | | | | | NR
US, Canada, Latin Amer, Western Europe, Eastern Europe, Australia/NZ, Finland, Denmark, Italy, Israel
FRACTURE PREVENTION TRIAL
Garcia-Delgado I et al., 1997 ^18^ | Not described | Not described | Yes | Yes | NR | NR | NR | NR/NR | NR | Yes | 1 | NR/NR/40 | Med known to affect skeleton, Hypogonadism | NR | Not reported | Yes | Source: Government; Role: NR | No
Calcitonin, Etidronate | | | | | | | | | | | | | | NR
Western Europe
Grant AM et al., 2005 ^19^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes/NR | NR | Yes | 4 | 15024/8827/5292 | Carcinoma or suspected carcinoma, Nephrolithiasis, Bisphosphonates, Calcitonin, Calcium (includes antacids), Fluoride, HRT, SERMS, Vitamin D, age < 70, nonambulatory, mental condition that would preclude participation, Hypercalcemia, life expectancy <1/2 years, fracture associated with bone abnormality | NR | Not reported | No | Source: Government & Industry; Role: described | Yes
Vitamin D | | | | | | | | | | | | | | NR
UK
Greenspan SL et al., 2003 ^20^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | NR/NR | No | Yes | 5 | 573/548/373 | Carcinoma or suspected carcinoma, Hyperthyroidism, Hyperparathyroidism, Hepatic insufficiency, Renal insufficiency, Anticonvulsants, Bisphosphonates, Calcitonin, Hormone use, Corticoids/Glucocorticoids, Med known to affect skeleton, Contraindication to HRT, Contraindication to alendronate, BMD hip T score >0.0 | Run-in period reported | Not reported | Yes | Source: Government; Role: described | Yes
Alendronate, Estrogen | | | | | | | | | | | | | | NR
US
Greenspan SL et al., 2006 ^21^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes/NR | No | Yes | 5 | 106/94/87 | Carcinoma or suspected carcinoma, Hyperparathyroidism, Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Malabsorption syndrome, age <18, Stage IV breast cancer, any medication that may alter bone and mineral metabolism | NR | Not reported | Yes | Source: 11110; Role: described | Yes
Risedronate | | | | | | | | | | | | | | NR
US
Grotz W et al., 2001 ^22^ | Not described | No | Yes | Yes | Yes | NR | No | Yes/NR | No | No | 2 | 114/98/80 | Kidney Pancreas Transplant | NR | Not reported | No | Source: Not reported | Limited
Ibandronate | | | | | | | | | | | | | | NR
Germany
Guanabens N et al., 2003 ^23^ | Yes | Not described | Yes | Yes | Yes | NR | NR | NR/NR | No | No | 3 | NR/NR/32 | Renal insufficiency, Upper GI, Bisphosphonates, Fluoride, Estrogen agonists (including estrogen), Corticoids/Glucocorticoids, Bilirubin >10mg/dL | NR | Yes | Yes | Source: Government; Role: described | No
Alendronate, Etidronate | | | | | | | | | | | | | | NR
Western Europe
Harris ST et al., 2001 ^24^ | Not described | Not described | Yes | Yes | NR | NR | NR | Yes/NR | NR | Yes | 2 | NR/NR/524 | Metabolic bone disorder other than osteoporosis, HRT, Med known to affect skeleton, Major systemic Disease, Abnormal Pap, Significant Psychiatric disease, LS spine abnormalities prohibiting DEXA | NR | Not reported | Yes | Source: Industry; Role: NR | Yes
Estrogen, Risedronate | | | | | | | | | | | | | | NR
US
Harris ST et al., 2004 ^25^ | Not described | Not described | Yes | Yes | Yes | Yes | Yes | Yes/NR | No | Yes | 3 | 4972/NR/1468 | Med known to affect skeleton, LS spine abnormalities prohibiting DEXA | NR | Not reported | Yes | Source: Industry; Role: NR | Yes
Risedronate | | | | | | | | | | | | | | NR
US, Canada
Hay JE et al., 2001 ^26^ | Not described | No | Yes | Yes | NR | No | No | NR/Yes | NR | Yes | 1 | NR/NR/63 | Hypothyroidism, Hyperthyroidism, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Anticonvulsants, Hormone use, Corticoids/Glucocorticoids, Med known to affect skeleton, Survived 6mos after liver transplant | NR | Not reported | Yes | Source: Industry; Role: NR | Yes
Calcitonin | | | | | | | | | | | | | | NR
US
Henderson S et al., 2006 ^27^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | NR/NR | No | No | 5 | NR/NR/61 | Pregnancy, Hepatic insufficiency, Bisphosphonates, HRT, Vitamin D deficient, Osteoporotic fracture, breast feeding, Hypercalcemia, Hypocalcemia | NR | Yes | Yes | Source: Industry; Role: NR | Yes
Risedronate | | | | | | | | | | | | | | NR
Australia/NZ
Hizmetli S et al., 1998 ^28^ | Not described | No | Yes | Yes | NR | No | No | NR/NR | NR | No | 1 | NR/NR/107 | Med known to affect skeleton, Secondary Osteoporosis | NR | Yes | Yes | Source: Not reported | Yes
Calcitonin | | | | | | | | | | | | | | NR
Turkey
Hochberg MC et al., 2005 ^29^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | NR/NR | NR | Yes | 4 | NR/NR/3658 | Cardiovascular disease, Hypothyroidism, Hyperthyroidism, Hyperparathyroidism, Hepatic insufficiency, Renal insufficiency, Malabsorption syndrome, Upper GI, Bisphosphonates, Calcitonin, Fluoride, Estrogen agonists (including estrogen), age >= 80, age <=55, life expectancy =<3yrs | NR | Yes | Yes | Source: Industry; Role: NR | Yes
Alendronate | | | | | | | | | | | | | | NR
US
FIT
Hodsman AB et al., 1997 ^30^ | Not described | Not described | Yes | Yes | NR | NR | NR | NR/NR | No | No | 2 | NR/NR/39 | Endocrine disease, Metabolic bone disorder other than osteoporosis, Bisphosphonates, Calcitonin, Corticoids/Glucocorticoids | NR | Not reported | No | Source: Government & Industry; Role: NR | Yes
Calcitonin, Raloxifene | | | | | | | | | | | | | | NR
Canada
Hooper MJ et al., 2005 ^31^ | Yes | Not described | Yes | Yes | NR | NR | NR | NR/NR | No | Yes | 3 | NR/NR/383 | Hyperthyroidism, Hyperparathyroidism, Metabolic bone disorder other than osteoporosis, Serum estradiol >20, Med known to affect skeleton | NR | Not reported | No | Source: Industry; Role: NR | Yes
Risedronate | | | | | | | | | | | | | | NR
Australia/NZ
Hosking D et al., 2003 ^32^ | Yes | Yes | Yes | Yes | NR | Yes | Yes | NR/NR | No | Yes | 5 | 1036/NR/549 | Hypothyroidism, Hyperthyroidism, Hyperparathyroidism, Metabolic bone disorder other than osteoporosis, Bisphosphonates, Fluoride, HRT, Estrogen agonists (including estrogen), Corticoids/Glucocorticoids, LS spine abnormalities prohibiting DEXA, Vitamin D deficient, Severe Upper GI symptoms, Severe Osteoporosis, age >90, age <60, Abnormal Urinary Calcium | NR | Not reported | No | Source: Industry; Role: NR | Yes
Alendronate, Risedronate | | | | | | | | | | | | | | NR
UK, Western Europe, Brazil
Ishida Y et al., 2004 ^33^ | Not described | Not described | Yes | Yes | Yes | NR | NR | NR/NR | No | Yes | 2 | 739/NR/396 | Age > 75, Carcinoma or suspected carcinoma, Metabolic bone disorder other than osteoporosis, Med known to affect skeleton, bilateral hip fractures, mental condition that would preclude participation | NR | Not reported | No | Source: Not reported | Yes
Calcitonin, Estrogen, Etidronate | | | | | | | | | | | | | | NR
Japan
YAMAGUCHI OP PREVENTION STUDY
Iwamoto J et al., 2003 ^34^ | Not described | Not described | Yes | Yes | NR | NR | No | NR/NR | No | Yes | 1 | NR/NR/50 | Metabolic bone disorder other than osteoporosis, HRT, Estrogen agonists (including estrogen), Med known to affect skeleton | NR | Yes | No | Source: Not reported | Yes
Alendronate, Etidronate | | | | | | | | | | | | | | NR
Japan
Iwamoto J et al., 2003 ^35^ | Not described | Not described | Yes | Yes | NR | NR | No | NR/NR | NR | No | 1 | NR/NR/40 | Metabolic bone disorder other than osteoporosis, HRT, Estrogen agonists (including estrogen), Med known to affect skeleton, any lumbar vertebral fractures | NR | Yes | No | Source: Not reported | Yes
Alendronate, Etidronate | | | | | | | | | | | | | | NR
Japan
Jackson RD et al., 2006 ^36^ | Yes | Not described | Yes | Yes | Yes | Yes | Yes | Yes/Yes | No | Yes | 4 | 68132/62528/36282 | Nephrolithiasis, Vitamin D, Corticoids/Glucocorticoids, age >= 80, Hypercalcemia, age <=50, life expectancy =<3yrs | NR | No | Yes | Source: Government & Industry; Role: described | Yes
Calcium, Vitamin D | | | | | | | | | | | | | | NR
US
WHI
Kanaji A et al., 2006 ^37^ | Not described | Not described | Yes | Yes | NR | Yes | Yes | NR/NR | NR | No | 4 | NR/NR/23 | any medication that may alter bone and mineral metabolism | NR | Not reported | Yes | Source: Not reported | Limited
Risedronate | | | | | | | | | | | | | | NR
Japan
Kananen K et al., 2005 ^38^ | Not described | Not described | Yes | Yes | NR | No | No | NR/Yes | No | No | 1 | 115/108/99 | Renal insufficiency, Myeloma | NR | Not reported | Yes | Source: Hospital, Industry & Private; Role: NR | Limited
Estrogen, Pamidronate, Testosterone | | | | | | | | | | | | | | NR
Finland
Kaufman JM et al., 2005 ^39^ | Yes | Not described | Yes | Yes | NR | Yes | NR | Yes/NR | NR | No | 4 | 959/437/355 | Age > 85, Carcinoma or suspected carcinoma, Hyperparathyroidism, Hypoparathyroidism, Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Sprue, Inflammatory bowel disease, Malabsorption syndrome, Nephrolithiasis, Urolithiasis, Anticonvulsants, Aluminum, Bisphosphonates, Calcitonin, Calcium (includes antacids), Coumarins, Fluoride, Androgen, Estrogen agonists (including estrogen), Progestin, Estrogen antagonists, Anabolic steroids, Vitamin D, Corticoids/Glucocorticoids, Abnormal Urinary Calcium, nonambulatory, any medication that may alter bone and mineral metabolism, treatment with calcitriol analogues, age<30, Secondary Osteoporosis, Alcohol Abuse, LS spine abnormalities prohibiting DEXA, treatment with indandione derivatives, Hypercalcemia, Hypocalcemia, Major systemic Disease, drug abuse, Growth Hormone deficiency, poor intestinal calcium absorption | Run-in period reported | Not reported | Yes | Source: Industry; Role: NR | Yes
PTH | | | | | | | | | | | | | | NR
US, Canada, Australia/NZ, Netherlands, Italy, Belgium, France, Spain, Sweden
Kim SH et al., 2004 ^40^ | Not described | Not described | Yes | Yes | NR | NR | NR | NR/NR | No | Yes | 2 | NR/NR/50 | Renal insufficiency, Bisphosphonates, bed rest | NR | Not reported | Yes | Source: Unclear; Role: NR | Limited
Pamidronate | | | | | | | | | | | | | | NR
Asia
Kishimoto H et al., 2006 ^41^ | Not described | Not described | Yes | Yes | Yes | Yes | Yes | NR/NR | No | Yes | 3 | NR/NR/496 | Carcinoma or suspected carcinoma, Cardiovascular disease, Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Gastrointestinal disease, Bisphosphonates, any medication that may alter bone and mineral metabolism, Drug Hypersensitivity, radiation therapy to lumbar spine or pelvis, LS spine abnormalities prohibiting DEXA | NR | Not reported | Yes | Source: Industry; Role: NR | Yes
Risedronate | | | | | | | | | | | | | | NR
Japan
Kushida K et al., 2004 ^42^ | Not described | Not described | Yes | Yes | Yes | NR | Yes | NR/NR | No | No | 4 | NR/NR/547 | Cardiovascular disease, Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Gastrointestinal disease, treatment with Risedronate or etidronate, Secondary Osteoporosis, radiographic findings that affect vertebral intensity, Med known to affect skeleton, malignancy under treatment with anti-tumor agents, radiation therapy to lumbar spine or pelvis | NR | Not reported | Yes | Source: Industry & Private; Role: NR | Yes
Etidronate, Risedronate | | | | | | | | | | | | | | NR
Japan
RESIDRONATE PHASE III RESEARCH III RESEARCH GROUP
Lindsay R et al., 1997 ^43^ | Yes | Yes | Yes | Yes | Yes | NR | No | Yes/NR | No | Yes | 3 | NR/NR/40 | Hypothyroidism, Hyperthyroidism, Hepatic insufficiency, Renal insufficiency, Nephrolithiasis, Secondary Osteoporosis | Run-in period reported | Not reported | No | Source: Government & Industry; Role: described | Yes
Estrogen, PTH | | | | | | | | | | | | | | NR
US
Lindsay R et al., 1999 ^44^ | Not described | Not described | Yes | Yes | NR | NR | NR | NR/NR | No | Yes | 1 | 1855/565/428 | Hyperthyroidism, Metabolic bone disorder other than osteoporosis, Upper GI, Bisphosphonates, Calcitonin | Run-in period reported | Not reported | Yes | Source: Industry; Role: NR | Yes
Alendronate, Estrogen | | | | | | | | | | | | | | NR
US
Luckey M et al., 2004 ^45^ | Yes | Yes | Yes | Yes | Yes | NR | Yes | NR/NR | No | Yes | 5 | 1200/508/456 | Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Upper GI, Venous thromboembolic disease - Active, Venous thromboembolic disease - Ever, Bisphosphonates, Fluoride, Estrogen agonists (including estrogen), SERMS, Anabolic steroids, Corticoids/Glucocorticoids, LS spine abnormalities prohibiting DEXA, Immunosuppressants, Hypocalcemia, previous PTH use, Med known to affect skeleton, Breast Cancer, Uterine Cancer | NR | Not reported | Yes | Source: Industry; Role: NR | Yes
Alendronate, Raloxifene | | | | | | | | | | | | | | NR
US
THE EFFECT STUDY
McClung MR et al., 2006 ^46^ | Yes | Not described | Yes | Yes | Yes | No | No | NR/NR | NR | Yes | 2 | NR/NR/412 | Hypothyroidism, Hyperthyroidism, Hyperparathyroidism, Hypoparathyroidism, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Malabsorption syndrome, Bisphosphonates, Calcitonin, Fluoride, Androgen, Estrogen agonists (including estrogen), SERMS, Estrogen antagonists, Testosterone, Vitamin D, Corticoids/Glucocorticoids, age >= 80, Hypocalcemia, LS spine abnormalities prohibiting DEXA, previous PTH use, Long bone fracture, greater than one vertebral fracture, Osteoporotic fracture within 2yrs | NR | Not reported | Yes | Source: Industry; Role: described | Yes
Alendronate, AMG162 | | | | | | | | | | | | | | NR
US
Milgrom C et al., 2004 ^47^ | Not described | Not described | Yes | Yes | NR | Yes | Yes | Yes/Yes | No | Yes | 4 | 473/473/324 | NR | NR | Not reported | Yes | Source: Government & Industry; Role: NR | Limited
Risedronate | | | | | | | | | | | | | | NR
Israel
Muscoso E et al., 2004 ^48^ | Not described | Not described | NR | Yes | NR | No | No | NR/NR | NR | No | 1 | NR/NR/2000 | NR | NR | Not reported | Yes | Source: Not reported | Yes
Alendronate, Raloxifene, Risedronate | | | | | | | | | | | | | | NR
Italy
Ninkovic M et al., 2002 ^49^ | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes/Yes | No | No | 2 | NR/NR/99 | Renal insufficiency, Bisphosphonates, retransplantation | NR | Yes | No | Source: Not reported | Limited
Pamidronate | | | | | | | | | | | | | | NR
UK
Orwoll ES et al., 2003 ^50^ | Yes | Yes | Yes | Yes | NR | Yes | Yes | Yes/NR | NR | Yes | 4 | 959/NR/437 | Age > 85, Carcinoma or suspected carcinoma, Hyperparathyroidism, Hypoparathyroidism, Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Sprue, Inflammatory bowel disease, Malabsorption syndrome, Nephrolithiasis, Urolithiasis, Anticonvulsants, Aluminum, Bisphosphonates, Calcitonin, Calcium (includes antacids), Coumarins, Fluoride, Estrogen agonists (including estrogen), Progestin, Estrogen antagonists, Anabolic steroids, Vitamin D, Corticoids/Glucocorticoids, age<30, Med known to affect skeleton, Alcohol Abuse, drug abuse, LS spine abnormalities prohibiting DEXA, Growth Hormone deficiency, treatment with indandione derivatives | NR | Yes | Yes | Source: Industry; Role: NR | Yes
PTH | | | | | | | | | | | | | | NR
1100101000
Palomba S et al., 2005 ^51^ | Yes | Not described | Yes | Yes | Yes | Yes | Yes | NR/NR | No | No | 4 | 279/97/90 | Carcinoma or suspected carcinoma, Endocrine disease, Hyperparathyroidism, Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Bisphosphonates, Calcitonin, Fluoride, HRT, Anabolic steroids, Proton pump inhibitors, Corticoids/Glucocorticoids, Vitamin D deficient, Hypercalcemia, Hypocalcemia, Med known to affect skeleton, hydrochlorothiazide, active rheumatoid arthritis, tobacco abuse, extremes of BMI (either high or low), other medications that could cause GI irritation | NR | Not reported | Yes | Source: Not reported | Yes
Risedronate | | | | | | | | | | | | | | NR
Italy
Porthouse J et al., 2005 ^52^ | Yes | Yes | Yes | Yes | No | No | No | Yes/Yes | NR | Yes | 2 | 11022/7944/3454 | Renal insufficiency, Nephrolithiasis, Urolithiasis, Calcium (includes antacids), age < 70, unable to give informed consent, Hypercalcemia, life expectancy <1/2 years | NR | Not reported | No | Source: Government & Industry; Role: described | Yes
Calcium, Vitamin D | | | | | | | | | | | | | | NR
UK
Prince RL et al., 2006 ^53^ | Yes | Yes | Yes | Yes | NR | Yes | Yes | Yes/NR | NR | Yes | 5 | 4312/1510/1460 | age < 70, participation in another trial, Med known to affect skeleton, Life expectancy <5 years | NR | Not reported | No | Source: Government; Role: described | Yes
Calcium | | | | | | | | | | | | | | NR
Australia/NZ
Quandt SA et al., 2005 ^54^ | Yes | Not described | Yes | Yes | Yes | Yes | Yes | Yes/NR | NR | No | 4 | NR/NR/3737 | Carcinoma or suspected carcinoma, Cardiovascular disease, Hyperparathyroidism, Hypoparathyroidism, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Malabsorption syndrome, Upper GI, Bisphosphonates, Calcitonin, Fluoride, Estrogen agonists (including estrogen), Progestin, Anabolic steroids, Corticoids/Glucocorticoids, BMD femoral neck < -3, noncompliance, history of bilateral hip replacement, nonambulatory, Alcohol Abuse, age <=55, age >= 80, Major systemic Disease, intending to move within four years, any vertebral deformity, recent major upper GI mucosal erosive disease, participation in another trial, unable to give informed consent, change in thyroid hormone dose, unexpected weight loss > 10% of ideal body weight in last 12 months | NR | No | No | Source: Industry; Role: NR | Yes
Alendronate | | | | | | | | | | | | | | NR
US
FIT
Ravn P et al., 1996 ^55^ | Not described | Not described | Yes | Yes | NR | NR | NR | NR/NR | No | No | 3 | NR/821/180 | Age > 75, Bisphosphonates, Calcitonin, HRT, Diseases, conditions or treatments known to interfere with calcium metabolism | NR | Not reported | Yes | Source: Not reported | Yes
Ibandronate | | | | | | | | | | | | | | NR
Western Europe
Recker R et al., 2004 ^56^ | Yes | Not described | Yes | Yes | Yes | Yes, but not described | Yes, but not described | NR/NR | No | No | 3 | 16632/NR/2862 | Carcinoma or suspected carcinoma, Hypothyroidism, Hyperthyroidism, Hyperparathyroidism, Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Gastrointestinal disease, Bisphosphonates, Calcitonin, Fluoride, HRT, Corticoids/Glucocorticoids, Alcohol Abuse, Med known to affect skeleton, Hypercalcemia, Hypocalcemia, Contraindication to Ca or Vitamin D, Cyclosporine | NR | Not reported | Yes | Source: Industry; Role: NR | Yes
Ibandronate | | | | | | | | | | | | | | NR
US, Western Europe
Recker RR et al., 2006 ^57^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes/NR | No | Yes | 4 | 5531/1840/1423 | Hypothyroidism, Hyperthyroidism, Hyperparathyroidism, Hypoparathyroidism, Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Upper GI, Venous thromboembolic disease, Bisphosphonates, Calcitonin, Fluoride, Androgen, Estrogen agonists (including estrogen), Progestin, SERMS, Estrogen antagonists, Anabolic steroids, Testosterone, Vitamin D, Corticoids/Glucocorticoids, any medication that may alter bone and mineral metabolism, Breast Cancer, previous PTH use, vaginal bleeding, age <=50, age > 80, T score<-4.0, fracture T4 to L4 | NR | Not reported | Yes | Source: Industry; Role: described | Yes
Alendronate, Raloxifene | | | | | | | | | | | | | | NR
US, Canada
EVA trial
Reginster JY et al., 2006 ^58^ | Yes | Yes | Yes | Yes | NR | Yes | Yes | Yes/NR | No | Yes | 4 | 2410/NR/1609 | Metabolic bone disorder other than osteoporosis, Renal insufficiency, Upper GI, Bisphosphonates, Fluoride, age > 80, Contraindication to Ca or Vitamin D | NR | Yes | Yes | Source: Industry; Role: NR | Yes
Ibandronate | | | | | | | | | | | | | | NR
US, Canada, Latin Amer, UK, Western Europe, Eastern Europe, Australia/NZ, South Africa
MOBILE
Reid IR et al., 1994 ^59^ | Not described | Not described | Yes | Yes | NR | Yes | Yes | Yes/NR | No | No | 4 | NR/NR/61 | Hypothyroidism, Hyperthyroidism, Hepatic insufficiency, Renal insufficiency, Anticonvulsants, Bisphosphonates, Calcitonin, Fluoride, HRT, Anabolic steroids, Corticoids/Glucocorticoids, Major systemic Disease, Hypercalcemia, Hypocalcemia | NR | Yes | No | Source: Government, Industry & Private; Role: NR | Yes
Pamidronate | | | | | | | | | | | | | | NR
Australia/NZ
Reid IR et al., 2002 ^60^ | Not described | Yes | Yes | Yes | Yes | Yes | Yes | NR/NR | NR | Yes | 3 | NR/NR/351 | Carcinoma or suspected carcinoma, Hypothyroidism, Hyperthyroidism, Hyperparathyroidism, Hypoparathyroidism, Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Bisphosphonates, Fluoride, HRT, Estrogen agonists (including estrogen), >1 Fracture, Vitamin D deficient, Med known to affect skeleton | NR | Yes | No | Source: Industry; Role: described | Yes
Zoledronic acid | | | | | | | | | | | | | | NR
Western Europe, Australia
Reid IR et al., 2004 ^61^ | Yes | Not described | Yes | Yes | Yes | NR | NR | NR/NR | No | Yes | 2 | NR/1522/619 | Hepatic insufficiency, Renal insufficiency, Venous thromboembolic disease - Ever, Anticonvulsants, Bisphosphonates, Calcitonin, Fluoride, Androgen, Estrogen agonists (including estrogen), Progestin, Lipid lowering agents, Vitamin D, Corticoids/Glucocorticoids, age <40, Endocrine disease requiring treatment except thyroid, FSH<40, excessive alcohol intake, >60 years, Breast Cancer, Estrogen Dependent CA, Any cancer except skin in last 5 years, Serious postmenopausal symptoms | NR | No | No | Source: Industry; Role: NR | Yes
Estrogen, Raloxifene | | | | | | | | | | | | | | NR
US, Canada, Western Europe, Australia/NZ, South Africa
Reid IR et al., 2006 ^62^ | Yes | Yes | Yes | Yes | NR | Yes | Yes | Yes/NR | No | Yes | 4 | 2421/1780/1471 | Carcinoma or suspected carcinoma, Hypothyroidism, Hyperthyroidism, Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Bisphosphonates, Calcium (includes antacids), HRT, Anabolic steroids, Corticoids/Glucocorticoids, age <=55, Med known to affect skeleton, Vitamin D deficient | NR | Not reported | Yes | Source: Unclear; Role: NR | Yes
Calcium | | | | | | | | | | | | | | NR
Australia/NZ
Ringe JD et al., 2006 ^63^ | Not described | Not described | Yes | Yes | Yes | No | No | NR/NR | NR | Yes | 1 | 580/NR/316 | Renal insufficiency, Bisphosphonates, Fluoride, Hypocalcemia, Drug Hypersensitivity | NR | Not reported | Yes | Source: Not reported | Yes
Risedronate | | | | | | | | | | | | | | NR
Germany
Rosen CJ et al., 2005 ^64^ | Yes | Not described | Yes | Yes | Yes | Yes | Yes | NR/NR | No | Yes | 4 | 1759/NR/1053 | Metabolic bone disorder other than osteoporosis, Upper GI, Bisphosphonates, Fluoride, HRT, Estrogen agonists (including estrogen), Anabolic steroids, Corticoids/Glucocorticoids, Immunosuppressants, previous PTH use, Inability to remain 30min upright, Vitamin D deficient | NR | Not reported | Yes | Source: Industry; Role: NR | Yes
Alendronate, Risedronate | | | | | | | | | | | | | | NR
US
FOSAMAX ACTONEL COMPARISON TRI
Sato S et al., 2003 ^65^ | Not described | Not described | Yes | Yes | Yes | No | No | NR/NR | NR | Yes | 1 | NR/NR/102 | Cardiovascular disease, Renal insufficiency, Med known to affect skeleton, LS spine abnormalities prohibiting DEXA | NR | Not reported | Yes | Source: Not reported | Yes
Etidronate | | | | | | | | | | | | | | NR
Japan
Sato Y et al., 2004 ^66^ | Yes | Not described | NR | Yes | NR | Yes, but not described | Yes, but not described | NR/NR | NR | No | 4 | NR/NR/80 | Cardiovascular disease, Hypothyroidism, Hyperthyroidism, Renal insufficiency, Bisphosphonates, Calcitonin, Estrogen agonists (including estrogen), Vitamin D, Corticoids/Glucocorticoids, nonambulatory, Underlying neurologic disorder, Prior calcium use | NR | Not reported | No | Source: Not reported | Limited
Etidronate | | | | | | | | | | | | | | NR
Japan
Sato Y et al., 2005 ^67^ | Yes | Yes | Yes | Yes | NR | NR | NR | Yes/NR | No | Yes | 4 | 312/287/280 | Cardiovascular disease, Hypothyroidism, Hyperthyroidism, Hyperparathyroidism, Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Upper GI, >1 Fracture, Familial Osteoporosis, Use of any drug known to alter bone metabolism for 3 months or longer during the preceding 12 months | NR | Not reported | No | Source: Not reported | Yes
Risedronate | | | | | | | | | | | | | | NR
Japan
Sato Y et al., 2005 ^68^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes, but not described | Yes/NR | No | Yes | 4 | 658/510/500 | Cardiovascular disease, Hypothyroidism, Hyperthyroidism, Hyperparathyroidism, Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Anticonvulsants, Bisphosphonates, Calcitonin, Calcium (includes antacids), Estrogen agonists (including estrogen), Vitamin D, Corticoids/Glucocorticoids, age < 70, treatment with Vitamin K, Familial Osteoporosis | NR | Not reported | Yes | Source: Not reported | Yes
Risedronate | | | | | | | | | | | | | | NR
Japan
Sato Y et al., 2005 ^69^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | NR/NR | NR | No | 4 | 137/NR/96 | Cardiovascular disease, Hypothyroidism, Hyperthyroidism, Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Anticonvulsants, Calcium (includes antacids), Vitamin D, dementia, total disability, hospitalization less than 2yrs, history of previous fracture, Drugs affecting Vitamin D Metabolism, Use of any drug known to alter bone metabolism for 3 months or longer during the preceding 12 months | NR | Not reported | No | Source: Not reported | Yes
Vitamin D | | | | | | | | | | | | | | NR
Japan
Sato Y et al., 2005 ^70^ | Yes | No | Yes | Yes | NR | Yes, but not described | Yes, but not described | NR/NR | No | No | 4 | NR/NR/374 | Cardiovascular disease, Hepatic insufficiency, Renal insufficiency, age <65, Med known to affect skeleton, mental condition that would preclude participation, inability to stand, quadraparesis, artificial nutrition | NR | Yes | No | Source: Not reported | Yes
Risedronate | | | | | | | | | | | | | | NR
Japan
Sato Y et al., 2005 ^71^ | Yes | Yes | Yes | Yes | Yes | NR | No | NR/NR | NR | No | 2 | NR/NR/200 | Cardiovascular disease, Hypothyroidism, Hyperthyroidism, Hyperparathyroidism, Renal insufficiency, Bisphosphonates, Calcitonin, Calcium (includes antacids), Estrogen agonists (including estrogen), Vitamin D, Corticoids/Glucocorticoids, age < 70, treatment with Vitamin K, nonambulatory, Diseases known to affect skeleton, nonvertebral fracture | NR | Not reported | No | Source: Not reported | Yes
Calcium, Vitamin D | | | | | | | | | | | | | | NR
Japan
Sato Y et al., 2006 ^72^ | Yes | Yes | Yes | Yes | Yes | NR | Yes | NR/NR | No | Yes | 5 | 558/NR/288 | Cardiovascular disease, Hypothyroidism, Hyperthyroidism, Hyperparathyroidism, Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Bisphosphonates, Calcitonin, Calcium (includes antacids), Estrogen agonists (including estrogen), Vitamin D, Corticoids/Glucocorticoids, treatment with Vitamin K, nonvertebral fracture, Stage 5 Parkinson's | NR | Not reported | No | Source: Not reported | Yes
Alendronate | | | | | | | | | | | | | | NR
Japan
Sato Y et al., 2006 ^73^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | NR/NR | No | Yes | 4 | 85/NR/82 | Med known to affect skeleton | NR | Not reported | Yes | Source: Not reported | Yes
Etidronate | | | | | | | | | | | | | | NR
Japan
Sorensen OH et al., 2003 ^74^ | Not described | Not described | Yes | Yes | Yes | Yes, but not described | Yes, but not described | NR/NR | NR | No | 2 | 4400/NR/1226 | Age > 85, Bisphosphonates, Calcitonin, Fluoride, Hormone use, Estrogen agonists (including estrogen), Progestin, Anabolic steroids, Vitamin D, LS spine abnormalities prohibiting DEXA, any medication that may alter bone and mineral metabolism, noncompliance | NR | Not reported | Yes | Source: Industry; Role: NR | Yes
Risedronate | | | | | | | | | | | | | | NR
UK, Western Europe, Eastern Europe, Australia/NZ
VERT
Tauchmanova L et al., 2006 ^75^ | Not described | Not described | Yes | Yes | NR | NR | No | NR/NR | No | Yes | 1 | NR/NR/60 | NR | NR | Yes | Yes | Source: Government; Role: NR | Yes
Estrogen, Risedronate, Zoledronic acid | | | | | | | | | | | | | | NR
Italy
Torres A et al., 2004 ^76^ | Not described | Not described | Yes | Yes | NR | Yes | Yes | NR/NR | No | No | 4 | NR/NR/90 | previous parathyroidectomy | NR | Not reported | Yes | Source: Government; Role: NR | Yes
Calcium, Vitamin D | | | | | | | | | | | | | | NR
Spain
Toth E et al., 2005 ^77^ | Not described | Not described | Yes | Yes | NR | No | No | NR/NR | No | Yes | 1 | 225/75/71 | Carcinoma or suspected carcinoma, Endocrine disease, Hypothyroidism, Hyperthyroidism, Hyperparathyroidism, Hypoparathyroidism, Hepatic insufficiency, Metabolic bone disorder other than osteoporosis, Renal insufficiency, Malabsorption syndrome, Upper GI, Anticonvulsants, Bisphosphonates, Anabolic steroids, Vitamin D, Corticoids/Glucocorticoids, treatment with monofluorophosphate, any vertebral deformity, Secondary Osteoporosis, Hypogonadism, any significant lab abnormalities, any medication that may alter bone and mineral metabolism | NR | Not reported | No | Source: Not reported | Yes
Calcitonin | | | | | | | | | | | | | | NR
Eastern Europe
Trovas GP et al., 2002 ^78^ | Not described | Not described | Yes | Yes | NR | Yes | Yes | NR/NR | No | Yes | 4 | NR/NR/28 | Metabolic bone disorder other than osteoporosis, Secondary Osteoporosis | NR | Not reported | No | Source: Industry; Role: NR | Yes
Calcitonin | | | | | | | | | | | | | | NR
Greece
Uchida S et al., 2005 ^79^ | Yes | Yes | Yes | Yes | Yes, but not described | Yes, but not described | Yes, but not described | NR/NR | NR | No | 3 | NR/NR/328 | Bisphosphonates, >1 Fracture | NR | Not reported | Yes | Source: Not reported | Yes
Alendronate | | | | | | | | | | | | | | NR
Japan
Ushiroyama T et al., 2001 ^80^ | Not described | No | Yes | Yes | NR | No | No | NR/NR | NR | Yes | 1 | NR/NR/202 | Metabolic bone disorder other than osteoporosis, Renal insufficiency, Urolithiasis, HRT, Estrogen agonists (including estrogen), Contraceptive | NR | Not reported | No | Source: Not reported | Yes
Calcitonin | | | | | | | | | | | | | | NR
Japan
Vogel VG et al., 2006 ^81^ | Yes | Not described | NR | Yes | Yes, but not described | Yes, but not described | Yes, but not described | Yes/NR | No | Yes | 3 | 184460/20168/19747 | Carcinoma or suspected carcinoma, Diabetes, Venous thromboembolic disease - Ever, Coumarins, Androgen, HRT, Estrogen agonists (including estrogen), Progestin, Estrogen antagonists, Contraceptive, age <35, mental condition that would preclude participation, cholestyramine, Uncontrolled HTN, atrial fibrillation, preformance status restricting activity | NR | Not reported | Yes | Source: Government & Industry; Role: described | Yes
Raloxifene, Tamoxifen | | | | | | | | | | | | | | NR
US, Canada
STAR P-2
Wimalawansa SJ, 1998 ^82^ | Yes | Yes | Yes | Yes | Yes | NR | No | NR/NR | No | No | 3 | 350/NR/72 | Metabolic bone disorder other than osteoporosis, Bisphosphonates, Calcitonin, Fluoride, HRT, Anabolic steroids, Corticoids/Glucocorticoids, oopherectomy, Med known to affect skeleton | NR | Yes | Yes | Source: Not reported | Yes
Estrogen, Etidronate | | | | | | | | | | | | | | NR
UK
Zein CO et al., 2005 ^83^ | Yes | No | Yes | Yes | Yes | Yes | Yes | NR/NR | No | No | 5 | NR/NR/34 | Hypothyroidism, Hyperthyroidism, Hyperparathyroidism, Renal insufficiency, Upper GI, Anticonvulsants, Calcitonin, Fluoride, Testosterone, Vitamin D, Corticoids/Glucocorticoids, heparin, Med known to affect skeleton, Vitamin D deficient, age >=70, age <18, starting estrogen within one year or discontinuing estrogen in the past | NR | Not reported | Yes | Source: Industry; Role: NR | Yes
Alendronate | | | | | | | | | | | | | | NR
US

### Reference List for Evidence Table C3

1 Agrawal S, Krueger DC, Engelke JA, et al. (2006). Between-meal risedronate does not alter bone turnover in nursing home residents. J Am Geriatr Soc.
2 Aris RM, Lester GE, Renner JB, et al. (2000). Efficacy of pamidronate for osteoporosis in patients with cystic fibrosis following lung transplantation. American journal of respiratory and critical care medicine.
3 Black DM, Delmas PD, Eastell R, et al. (2007). Once-yearly zoledronic acid for treatment of postmenopausal osteoporosis. N Engl J Med.
4 Body JJ, Gaich GA, Scheele WH, et al. (2002). A randomized double-blind trial to compare the efficacy of teriparatide. J Clin Endocrinol Metab.
5 Bone HG, Greenspan SL, McKeever C, et al. (2000). Alendronate and estrogen effects in postmenopausal women with low bone mineral density. Alendronate/Estrogen Study Group. J Clin Endocrinol Metab.
6 Bonnick S, Saag KG, Kiel DP, et al. Comparison of Weekly Treatment of Postmenopausal Osteoporosis with Alendronate versus Risedronate Over Two Years. J Clin Endocrinol Metab 2006.
7 Boutsen Y, Jamart J, Esselinckx W, et al. (1997). Primary prevention of glucocorticoid-induced osteoporosis with intermittent intravenous pamidronate: a randomized trial. Calcif Tissue Int.
8 Brown JP, Kendler DL, McClung MR, et al. (2002). The efficacy and tolerability of risedronate once a week for the treatment of postmenopausal osteoporosis. Calcif Tissue Int.
9 Campbell IA, Douglas JG, Francis RM, et al. (2004). Five year study of etidronate and/or calcium as prevention and treatment for osteoporosis and fractures in patients with asthma receiving long term oral and/or inhaled glucocorticoids. Thorax.
10 Chapurlat RD, Palermo L, Ramsay P, et al. (2005). Risk of fracture among women who lose bone density during treatment with alendronate. The Fracture Intervention Trial. Osteoporos Int.
11 Chesnut CH, Skag A, Christiansen C, et al. (2004). Effects of oral ibandronate administered daily or intermittently on fracture risk in postmenopausal osteoporosis. Journal of bone and mineral research : the official journal of the American Society for Bone and Mineral Research.
12 Coco M, Glicklich D, Faugere MC, et al. (2003). Prevention of bone loss in renal transplant recipients: a prospective, randomized trial of intravenous pamidronate. Journal of the American Society of Nephrology : JASN.
13 Cosman F, Nieves J, Woelfert L, et al. (2001). Parathyroid hormone added to established hormone therapy: effects on vertebral fracture and maintenance of bone mass after parathyroid hormone withdrawal. J Bone Miner Res.
14 Cosman F, Nieves J, Zion M, et al. (2005). Daily and cyclic parathyroid hormone in women receiving alendronate. N Engl J Med.
15 Fisher B, Costantino JP, Wickerham DL, et al. (1998). Tamoxifen for prevention of breast cancer: report of the National Surgical Adjuvant Breast and Bowel Project P-1 Study. J Natl Cancer Inst.
16 Fukunaga M, Kushida K, Kishimoto H, et al. (2002). A comparison of the effect of risedronate and etidronate on lumbar bone mineral density in Japanese patients with osteoporosis: a randomized controlled trial. Osteoporos Int.
17 Gallagher JC, Genant HK, Crans GG, et al. (2005). Teriparatide reduces the fracture risk associated with increasing number and severity of osteoporotic fractures. The Journal of clinical endocrinology and metabolism.
18 Garcia-Delgado I PSG-FLRERJHF. Calcitonin, etidronate, and calcidiol treatment in bone loss after cardiac transplantation. Calcified tissue international 1997;60(2):155–9.
19 Grant AM, Avenell A, Campbell MK, et al. (2005). Oral vitamin D3 and calcium for secondary prevention of low-trauma fractures in elderly people (Randomised Evaluation of Calcium Or vitamin D, RECORD): a randomised placebo-controlled trial. Lancet.
20 Greenspan SL, Resnick NM, Parker RA. (2003). Combination therapy with hormone replacement and alendronate for prevention of bone loss in elderly women: a randomized controlled trial. JAMA.
21 Greenspan SL, Bhattacharya RK, Sereika SM, et al. Prevention of Bone Loss in Survivors of Breast Cancer: A Randomized, Double-Blind, Placebo-Controlled Clinical Trial. J Clin Endocrinol Metab 2006.
22 Grotz W, Nagel C, Poeschel D, et al. (2001). Effect of ibandronate on bone loss and renal function after kidney transplantation. Journal of the American Society of Nephrology : JASN.
23 Guanabens N PARIALPFCLMAMdOMRMPPRJ. Alendronate is more effective than etidronate for increasing bone mass in osteopenic patients with primary biliary cirrhosis. The American journal of gastroenterology 2003;98(10):2268–74.
24 Harris ST, Eriksen EF, Davidson M, et al. (2001). Effect of combined risedronate and hormone replacement therapies on bone mineral density in postmenopausal women. J Clin Endocrinol Metab.
25 Harris ST, Watts NB, Li Z, et al. (2004). Two-year efficacy and tolerability of risedronate once a week for the treatment of women with postmenopausal osteoporosis. Curr Med Res Opin.
26 Hay JE, Malinchoc M, Dickson ER. (2001). A controlled trial of calcitonin therapy for the prevention of post-liver transplantation atraumatic fractures in patients with primary biliary cirrhosis and primary sclerosing cholangitis. J Hepatol.
27 Henderson S, Hoffman N, Prince R. (2006). A double-blind placebo-controlled study of the effects of the bisphosphonate risedronate on bone mass in patients with inflammatory bowel disease. Am J Gastroenterol.
28 Hizmetli S, Elden H, Kaptanoglu E, et al. (1998). The effect of different doses of calcitonin on bone mineral density and fracture risk in postmenopausal osteoporosis. Int J Clin Pract.
29 Hochberg MC, Thompson DE, Black DM, et al. (2005). Effect of alendronate on the age-specific incidence of symptomatic osteoporotic fractures. J Bone Miner Res.
30 Hodsman AB, Fraher LJ, Watson PH, et al. (1997). A randomized controlled trial to compare the efficacy of cyclical parathyroid hormone versus cyclical parathyroid hormone and sequential calcitonin to improve bone mass in postmenopausal women with osteoporosis. The Journal of clinical endocrinology and metabolism.
31 Hooper MJ, Ebeling PR, Roberts AP, et al. (2005). Risedronate prevents bone loss in early postmenopausal women: a prospective randomized, placebo-controlled trial. Climacteric.
32 Hosking D, Adami S, Felsenberg D, et al. (2003). Comparison of change in bone resorption and bone mineral density with once-weekly alendronate and daily risedronate: a randomised, placebo-controlled study. Current medical research and opinion.
33 Ishida Y, Kawai S. (2004). Comparative efficacy of hormone replacement therapy, etidronate, calcitonin, alfacalcidol, and vitamin K in postmenopausal women with osteoporosis: The Yamaguchi Osteoporosis Prevention Study. The American Journal of Medicine.
34 Iwamoto J, Takeda T, Ichimura S, et al. (2003). Comparative effects of treatment with etidronate and alendronate on bone resorption, back pain, and activities of daily living in elderly women with vertebral fractures. Keio J Med.
35 Iwamoto J, Takeda T, Ichimura S, et al. (2003). Early response to alendronate after treatment with etidronate in postmenopausal women with osteoporosis. Keio J Med.
36 Jackson RD, LaCroix AZ, Gass M, et al. (2006). Calcium plus vitamin D supplementation and the risk of fractures. N Engl J Med.
37 Kanaji A, Higashi M, Namisato M, et al. (2006). Effects of risedronate on lumbar bone mineral density, bone resorption, and incidence of vertebral fracture in elderly male patients with leprosy. Lepr Rev.
38 Kananen K, Volin L, Laitinen K, et al. (2005). Prevention of bone loss after allogeneic stem cell transplantation by calcium, vitamin D, and sex hormone replacement with or without pamidronate. J Clin Endocrinol Metab.
39 Kaufman JM, Orwoll E, Goemaere S, et al. (2005). Teriparatide effects on vertebral fractures and bone mineral density in men with osteoporosis: treatment and discontinuation of therapy. Osteoporos Int.
40 Kim SH, Lim SK, Hahn JS. (2004). Effect of pamidronate on new vertebral fractures and bone mineral density in patients with malignant lymphoma receiving chemotherapy. The American journal of medicine.
41 Kishimoto H, Fukunaga M, Kushida K, et al. (2006). Efficacy and tolerability of once-weekly administration of 17.5 mg risedronate in Japanese patients with involutional osteoporosis: a comparison with 2.5-mg once-daily dosage regimen. J Bone Miner Metab.
42 Kushida K, Fukunaga M, Kishimoto H, et al. (2004). A comparison of incidences of vertebral fracture in Japanese patients with involutional osteoporosis treated with risedronate and etidronate: a randomized, double-masked trial. Journal of Bone and Mineral Metabolism.
43 Lindsay R, Nieves J, Formica C, et al. (1997). Randomised controlled study of effect of parathyroid hormone on vertebral-bone mass and fracture incidence among postmenopausal women on oestrogen with osteoporosis. Lancet.
44 Lindsay R, Cosman F, Lobo RA, et al. (1999). Addition of alendronate to ongoing hormone replacement therapy in the treatment of osteoporosis: a randomized, controlled clinical trial. The Journal of clinical endocrinology and metabolism.
45 Luckey M, Kagan R, Greenspan S, et al. (2004). Once-weekly alendronate 70 mg and raloxifene 60 mg daily in the treatment of postmenopausal osteoporosis. Menopause.
46 McClung MR, Lewiecki EM, Cohen SB, et al. (2006). Denosumab in postmenopausal women with low bone mineral density. N Engl J Med.
47 Milgrom C, Finestone A, Novack V, et al. (2004). The effect of prophylactic treatment with risedronate on stress fracture incidence among infantry recruits. Bone.
48 Muscoso E, Puglisi N, Mamazza C, et al. (2004). Antiresorption therapy and reduction in fracture susceptibility in the osteoporotic elderly patient: open study. Eur Rev Med Pharmacol Sci.
49 Ninkovic M, Love S, Tom BD, et al. (2002). Lack of effect of intravenous pamidronate on fracture incidence and bone mineral density after orthotopic liver transplantation. J Hepatol.
50 Orwoll ES, Scheele WH, Paul S. (2003). The effects of teriparatide[human parathyroid hormone(1–34)] therapy on bone density in men with osteoporosis. J Bone Miner Res.
51 Palomba S, Orio F, Manguso F, et al. (2005). Efficacy of risedronate administration in osteoporotic postmenopausal women affected by inflammatory bowel disease. Osteoporos Int.
52 Porthouse J, Cockayne S, King C, et al. (2005). Randomised controlled trial of calcium and supplementation with cholecalciferol (vitamin D3) for prevention of fractures in primary care. BMJ.
53 Prince RL, Devine A, Dhaliwal SS, et al. (2006). Effects of calcium supplementation on clinical fracture and bone structure: results of a 5-year, double-blind, placebo-controlled trial in elderly women. Arch Intern Med.
54 Quandt SA, Thompson DE, Schneider DL, et al. (2005). Effect of alendronate on vertebral fracture risk in women with bone mineral density T scores of-1.6 to -2.5 at the femoral neck: the Fracture Intervention Trial. Mayo Clin Proc.
55 Ravn P, Clemmesen B, Riis BJ, et al. (1996). The effect on bone mass and bone markers of different doses of ibandronate: a new bisphosphonate for prevention and treatment of postmenopausal osteoporosis: a 1-year, randomized, double-blind, placebo-controlled dose-finding study. Bone.
56 Recker R, Stakkestad JA, Chesnut CH, et al. (2004). Insufficiently dosed intravenous ibandronate injections are associated with suboptimal antifracture efficacy in postmenopausal osteoporosis. Bone.
57 Recker RR, Kendler D, Recknor CP, et al. Comparative effects of raloxifene and alendronate on fracture outcomes in postmenopausal women with low bone mass. Bone 2006.
58 Reginster JY, Adami S, Lakatos P, et al. (2006). Efficacy and tolerability of once-monthly oral ibandronate in postmenopausal osteoporosis: 2 year results from the MOBILE study. Ann Rheum Dis.
59 Reid IR, Wattie DJ, Evans MC, et al. (1994). Continuous therapy with pamidronate, a potent bisphosphonate, in postmenopausal osteoporosis. J Clin Endocrinol Metab.
60 Reid IR, Brown JP, Burckhardt P, et al. (2002). Intravenous zoledronic acid in postmenopausal women with low bone mineral density. N Engl J Med.
61 Reid IR, Eastell R, Fogelman I, et al. (2004). A comparison of the effects of raloxifene and conjugated equine estrogen on bone and lipids in healthy postmenopausal women. Arch Intern Med.
62 Reid IR, Mason B, Horne A, et al. (2006). Randomized controlled trial of calcium in healthy older women. Am J Med.
63 Ringe JD, Faber H, Farahmand P, et al. (2006). Efficacy of risedronate in men with primary and secondary osteoporosis: results of a 1-year study. Rheumatol Int.
64 Rosen CJ, Hochberg MC, Bonnick SL, et al. (2005). Treatment with once-weekly alendronate 70 mg compared with once-weekly risedronate 35 mg in women with postmenopausal osteoporosis: a randomized double-blind study. J Bone Miner Res.
65 Sato S, Ohosone Y, Suwa A, et al. (2003). Effect of intermittent cyclical etidronate therapy on corticosteroid induced osteoporosis in Japanese patients with connective tissue disease: 3 year followup. J Rheumatol.
66 Sato Y, Kanoko T, Yasuda H, et al. (2004). Beneficial effect of etidronate therapy in immobilized hip fracture patients. Am J Phys Med Rehabil.
67 Sato Y, Iwamoto J, Kanoko T, et al. (2005). Risedronate sodium therapy for prevention of hip fracture in men 65 years or older after stroke. Arch Intern Med.
68 Sato Y, Kanoko T, Satoh K, et al. (2005). The prevention of hip fracture with risedronate and ergocalciferol plus calcium supplementation in elderly women with Alzheimer disease: a randomized controlled trial. Arch Intern Med.
69 Sato Y IJKTSK. Low-dose vitamin D prevents muscular atrophy and reduces falls and hip fractures in women after stroke: a randomized controlled trial. Cerebrovasc Dis 2005;20(3):187–92.
70 Sato Y, Iwamoto J, Kanoko T, et al. (2005). Risedronate therapy for prevention of hip fracture after stroke in elderly women. Neurology.
71 Sato Y, Kanoko T, Satoh K, et al. (2005). Menatetrenone and vitamin D2 with calcium supplements prevent nonvertebral fracture in elderly women with Alzheimer's disease. Bone.
72 Sato Y, Iwamoto J, Kanoko T, et al. Alendronate and vitamin D2 for prevention of hip fracture in Parkinson's disease: A randomized controlled trial. Mov Disord 2006.
73 Sato Y, Honda Y, Iwamoto J. Etidronate for fracture prevention in amyotrophic lateral sclerosis: A randomized controlled trial. Bone 2006.
74 Sorensen OH, Crawford GM, Mulder H, et al. (2003). Long-term efficacy of risedronate: a 5-year placebo-controlled clinical experience. Bone.
75 Tauchmanova L, De Simone G, Musella T, et al. (2006). Effects of various antireabsorptive treatments on bone mineral density in hypogonadal young women after allogeneic stem cell transplantation. Bone Marrow Transplant.
76 Torres A, Garcia S, Gomez A, et al. (2004). Treatment with intermittent calcitriol and calcium reduces bone loss after renal transplantation. Kidney Int.
77 Toth E, Csupor E, Meszaros S, et al. (2005). The effect of intranasal salmon calcitonin therapy on bone mineral density in idiopathic male osteoporosis without vertebral fractures—an open label study. Bone.
78 Trovas GP, Lyritis GP, Galanos A, et al. (2002). A randomized trial of nasal spray salmon calcitonin in men with idiopathic osteoporosis: effects on bone mineral density and bone markers. J Bone Miner Res.
79 Uchida S, Taniguchi T, Shimizu T, et al. (2005). Therapeutic effects of alendronate 35 mg once weekly and 5 mg once daily in Japanese patients with osteoporosis: a double-blind, randomized study. J Bone Miner Metab.
80 Ushiroyama T, Ikeda A, Sakai M, et al. (2001). Effects of the combined use of calcitonin and 1 alpha-hydroxycholecalciferol on vertebral bone loss and bone turnover in women with postmenopausal osteopenia and osteoporosis: a prospective study of long-term and continuous administration with low dose calcitonin. Maturitas.
81 Vogel VG, Costantino JP, Wickerham DL, et al. (2006). Effects of tamoxifen vs raloxifene on the risk of developing invasive breast cancer and other disease outcomes: the NSABP Study of Tamoxifen and Raloxifene (STAR) P-2 trial. Jama.
82 Wimalawansa SJ. (1998). A four-year randomized controlled trial of hormone replacement and bisphosphonate, alone or in combination, in women with postmenopausal osteoporosis. Am J Med.
83 Zein CO, Jorgensen RA, Clarke B, et al. (2005). Alendronate improves bone mineral density in primary biliary cirrhosis: a randomized placebo-controlled trial. Hepatology.

## Evidence Table C4. Systematic Reviews Data Evidence Table

Evidence Table C4. Systematic Reviews Data Evidence Table

Author, Year | (1) Aims | (2) Time period covered | (3) Eligibility criteria | (4) Number of patients | (5) Characteristics of identified articles: Study designs | (6) Characteristics of identified articles: Populations | (7) Characteristics of identified articles: Interventions | (8) Main results | (9) Subgroups | (10) Adverse events | (11) Comments
Torgerson, 2001 ^1^ | Determine if HRT reduced vertebral fractures | All trials until end of August 2001 | (1) RCT of HRT where women had been randomized to at least 12 mon. of HRT or to no HRT. | 6,723 | 13 RCTs | Postmenopausal women | Estrogens (transdermal estradiol-.1mg,50ug; oral estradiol-1mg,2mg; oral conjugated estrogens-.625mg,.3mg) | HRT use is associated with reduction in vertebral fractures, particularly among osteoporotic women. | None | Not reported
Crannery, 2001 ^2^ | Review the effect of etidronate on bone density & fractures in post menopausal women. | 1966-1998 | (1) RCTs of at least 1yr duration comparing etidronate therapy with placebo or with calcium and/or vitamin D, 2)outcomes included fracture incidence or bone density and 3)participants were postmenopausal women | 1,267 | 13 RCTs; all published and unpublished RCTs | Postmenopausal women | Intermittent cyclical method of administration of etidronate at 400mg per day for 14–20 days followed by 56–91 days of calcium and/or vitamin D; duration 1–3 years | Beneficial effect of etidronate on reducing vertebral fractures with an associated increase in lumbar spine bone density; data suggested a reduction in vertebral fractures with a pooled relative risk of 0.63 (95% CI 0.44 to 0.92); there was no effect on nonvertebral fractures (relative risk 0.99 (95% CI 0.69 to 1.42). | None | Not reported
Wells, 2002 ^3^ | Review the effects of HRT on bone density and fractures in postmenopausal women. | 1966-1999 | (1) RCT in postmenopausal women that compared an HRT intervention (estrogen used alone or estrogen opposed by progestin) with a placebo (2)HRT could be given in conjunction with a calcium and vitamin D, provided the other group received the same (3)results had to be reported with a follow up of at least one year on one or more of the outcomes of interest (4) both prevention and rx trials were accepted (rx referring to studies that included women w/ prevalent #'s at baseline) | 9,958 | 57 RCTs | Postmenopausal women | HRT preparations (estrogen-progestin preparation were diverse); 1–5 years duration | Data shows a nonsignificant trend toward a reduced incidence in vertebral and nonvertebral fractures; HRT has a consistent, favorable and large effect on bone density at all sites. | | Not reported
Cranney, 2002 ^4^ | Review the effects of risedronate on bone density & #'s in post menopausal women | 1966 to the end of 2000 | (1) Randomized, placebo-controlled trials of risedronate for osteoporosis in postmenopausal women defined as greater than 6 months postmenopausal); 2)follow up of at least one year; and 3)fracture incidence or bone mineral density data available | 14,832 | 8 RCTs | Postmenopausal women (defined as greater than 6 mon. post menopausal) | Risedronate 2.5mg; risedronate 5.0mg; duration 1–3 years | The 5mg daily dose of risedronate tended to show a larger impact on bone density than did the 2.5mg dose or cyclic administration; longer duration of therapy produced larger effects; risedronate produces a substantial reduction of vertebral and nonvertebral fractures; the pooled relative risk for vertebral fractures in women given 2.5mg or more was 0.64 (95% CI 0.54 to 0.77); the pooled rr of nonvertebral fractures in patients given 2.5mg or more was 0.73 (95% CI 0.61 to 0.87) | | Treatment had little or no impact on the risk of discontinuing medication (rr 0.94; 95% CI 0.80, 1.10); for discontinuation due to gastrointestinal side effects, the pooled rr was 0.97 (95% CI 0.90, 1.04);the pooled rr for dyspepsia and abdominal pain were similar; for esophagitis, the pooled rr from 5 trials was 0.91(95% CI 0.70,1.18) | The serious methodological limitation of these studies is the consistently very high loss to follow up
Cranney, 2002 ^5^ | Review the effect of alendronate on bone density and fractures in post menopausal women. | 1980-1999 | (1) RCTs comparing postmenopausal women receiving alendronate to those not receiving alendronate with follow up of at least 1 year; and 2)fracture incidence, or bmd data | 12,855 | 11 RCTs | Postmenopausal women | Alendronate 1mg–40mg; duration 1–4yrs | Alendronate increases bone density in both early post menopausal and those with established osteoporosis while reducing the rate of vertebral fracture over 2–3 years of treatment; the pooled relative risk for vertebral fractures in patients given 5mg or more of alendronate was 0.52 (95%ci,0.43–0.65); the rr of nonvertebral fractures in patients given 10 mg or more was 0.51 (95% CI 0.38–0.69) | | The relative risk for discontinuing alendronate (5mg or greater) due to adverse effects was 1.15 (95% CI 0.93–1.42); the pooled rr for discontinuing medication due to gastrointestinal side effects for 5mg or grater was 1.03(0.81–1.30, p=0.83) and the pooled rr for gastrointestinal adverse effects with continuation of medication was 1.03 (0.98–1.07) p=0.23 | The major methodological limitation was the loss to follow up; another limitation is the length of follow up, 4years or less in all studies to date
Cranney, 2002 ^6^ | Review the effect of calcitonin on bone density and fractures in postmenopausal women | 1966-2000 | (1) RCTs of at least 1-yr duration, comparing calcitonin therapy vs. placebo or calcium and/or vitamin D; 2)outcomes included bmd or fracture incidence; and 3)participants were postmenopausal women | 3,993 | 30 RCTs | Postmenopausal women | Calcitonin 40iu–400iu; salmon calcitonin; esl calcitonin; duration 1–5yrs; 1m, intranasal, suppository | Calcitonin likely increases bone density in postmenopausal women predominantly at the lumbar spine and forearm for weekly doses greater than 250 iu, although the true effect may be smaller than the pooled estimate would suggest; calcitonin likely reduces the risk of vertebral fractures; its effect on nonvertebral fractures remains uncertain | | According to the authors in general the trials were poor in their reporting of adverse events | Large loss to follow up, particularly in the proof trials
Karpf, 1997 ^7^ | To evaluate the effect of treatment with alendronate sodium, on the incidence of nonvertebral fractures in postmenopausal women with osteoporosis | All completed prospective, randomized, placebo-controlled alendronate trails of at least two years duration | All postmenopausal women randomized to treatment with placebo or alendronate at a dose higher than 1mg per day for at least 2 year that evaluated the efficacy of treatment | 1,602 | 5 RCTs | Women with osteoporosis between ages of 42 & 85 years, postmenopausal at least four years, with lumbar spine bone mineral density at least 2.0 sd below the mean for young adult woman; all received 500mg of ca and were screened for vit d deficiency | Alendronate dose higher than 1mg per day for at least 2yrs;alendronate; 1mg, 2.5mg, 5mg, 10mg, 20/0mg, 20/5 mg, 40/0mg, 40/2.5mg; all received calcium 500mg and were screened for vitamin D deficiency | In postmenopausal women with osteoporosis, treatment with alendronate reduces the risk of nonvertebral fractures over at least 3 years; the estimated cumulative of nonvertebral fractures after 3 years was 12.6%in the placebo group and 9.0% in the alendronate group; the relative risk for nonvertebral fractures estimated using cox model was 0.71(95% CI, 0.502–0.997)(p=.048) | | Not reported | A limitation was that nonvertebral fractures were self reported; however, all fractures were confirmed by radiography or by physician examination, and self report has been shown to be accurate for most nonvertebral fracture; another possible criticism in the individual studies is that nonvertebral fractures were captured as safety end points, as opposed to efficacy end points
Papapoulos, 2004 ^8^ | Assess consistency of the effect of alendronate in reducing the risk of hip fractures among different studies & populations. | All randomized clinical trials w/ alendronate | Aimed to included all RCT with alendronate in postmenopausal women with a t-score of 2.0 or less, or w/ a vertebral # in which there were sufficient data to evaluate the relative risk; specifically there was at least one patient in each treatment group that experienced a hip fracture | 9,023 | 6 RCTs; one study listed as active-control, rest were placebo control | Postmenopausal women w/a t score of less than equal to 2.0, or w/a vertebral # | Alendronate 5–20mg/day; duration of studies 1–4.5years | Therapy with alendronate is associated with significant and clinically important reductions in the incidence of hip fractures in women with postmenopausal osteoporosis. | In patients with a t-score of less than or equal to -2.0, or with a vertebral fracture, the effect of hip fracture risk consistently favored patients receiving alendronate therapy, with an overall reduction in risk of hip fracture of 45% (95% CI 16% to 64%, p=0.007); for patients who met the criteria of osteoporosis as defined by the who, the overall risk reduction was 55% (95% CI 29% to 72%, p=0.0008). | Not reported | Limitations: 1.primarily Caucasian women only 2.not all studies can be classified as fracture studies and thus the question arises whether all the trials should be weighted equally
Cranney, 2000 ^9^ | Review the efficacy of calcitonin (subcutaneous or nasal) for the treatment & prevention of corticosteroid induced osteoporosis | Up to May 1998 | RCT that used calcitonin for the prevention or treatment of steroid induced osteoporosis; men or women over age 18 with any underlying disease requiring therapy with steroids; randomized allocation of patients into treatment groups; adequate description of the intervention medications in terms of dosage scheduling and administration | 441 | 9 RCTs | Men or woman over age of 18, with any underlying disease that requires therapy with systematic steroids | Calcitonin; intranasal 100iu, 200iu, 400iu, 50iu, 100iu; control groups received placebo or were untreated; ca+vitd were accepted in control group if they were also given in equal doses to the treated group | Calcitonin has not yet demonstrated effectiveness at preventing fractures with steroid induced osteoporosis; calcitonin appears to prevent bone loss at the lumbar spine by about 3% in the first year; effect on bone density is greater in patients taking corticosteroids for more than 3 months; no consistent effect of different dosages; subcutaneous calcitonin showed greater prevention of bone loss (may be due to greater bioavailability of drug) | | Flushing rashes & nausea- these were increased in calcitonin group relative to control group | All trials had small sample sizes (less than 40 per group);
Cranney, 2003 ^10^ | Review efficiency of risedronate on bone density and fracture reduction in postmenopausal women. | 1990-2001 | Randomized women to risedronate or an alternative (placebo or calcium and/or vit d. D) and measured bmd for at least 1yr) | 14,500 | 8 RCTs | Postmenopausal women - 2 major groups of women included were those with mild bone less (prevention) or those with more severe bone less as defined by a t score <-2.0 sd or prevalent vertebral facture (treatment) | Risedronate dosages included 2.5mg cyclical, 2.5 mg/d, 5mg cyclical, & 5mg/d for durations of at least one year | There is good evidence for the efficacy of risedronate in the reduction of both vertebral and non vertebral fractures; risedronate is able to achieve this without increasing risk for overall withdrawals due to adverse effects. | Vertebral fractures: 1.prevention population - the relative risk was 2.43 (95% CI 0.12–49.43) 2. treatment population-estimate of rr using random effects model was 0.63 (95% CI 0.52–0.77);p<0.01. nonvertebral fracture: 1.prevention population-rr was 0.48 (95% CI 0.10–2.26) 2.treatment population -pooled estimate of rr was 0.73(95% CI 0.61–0.88);p<0.01
Cranney, 2001 ^11^ | Review the efficacy of etidronate therapy in the prevention and treatment of postmenopausal osteoporosis | 1966-1998 | Trials that randomized postmenopausal women to etidronate or an alternative (placebo or calcium and /or vitamin D) and measured bone density for at least 1 year | 1,010 | 13 RCTs | Postmenopausal women | Intermittent cyclic method of administration of etidronate at 400mg per day for 14–20 days followed by calcium and/or vitamin D | Data suggested a reduction in vertebral fractures with a pooled relative risk of 0.60% (95% CI 0.41–0.88); there was no effect on nonvertebral fractures; etidronate increases bone density at the lumbar spine and the femoral neck ; effects were larger at 4 years, though the numbers of patients followed was much smaller. | The treatment effect of etidronate was consistent across subgroups: prevention(rr:0.61) vs. treatment(rr:0.59) | The pooled estimate showed no statistical difference between placebo and etidronate for the risk of withdrawal overall (rr:0.89, 95% ci:0.71–1.13), with consistency across studies; drop out due to side effects (rr:1.51(0.69 to 3.32), consistent across studies
Farquhar, 2005 ^12^ | To assess the effect of long-term hormone therapy on mortality, heart disease, venous thromboembolism, stroke, transient ischemic attacks, breast cancer, colorectal cancer, ovarian cancer, endometrial cancer, gallbladder disease, cognitive function, dementia, fractures, and quality of life | Up to 2004 | Randomized double blind trials of hormone therapy (estrogens with or without progestogens) versus placebo, taken for at least one year by perimenopausal or postmenopausal women | 35,089 | 15 RCTs | Perimenopausal (women with spontaneous menopause who had menstruated irregularly within the last 12 months) and postmenopausal (surgical menopause or women with spontaneous menopause and amenorrhea for more than 12 months) women recruited from any health | All estrogens with or without progestins, administered by oral, transdermal, subcutaneous, or intranasal routes; trials lasted 1 to 10 years | Hormone therapy offered the benefit of a significant reduction in the risk of fracture (no greater in women at high risk of fractures) but only after 4 or 5 years of treatment. | | Studies included a range of adverse effects doubling or tripling of the risk of thromboembolic events, a large increase in endometrial cancer risk in women taking estrogen without progestogen, an increased incidence of gallbladder disease and a possible link between hormone therapy and breast cancer, significantly increased incidence of stroke; significantly increased risk of coronary events and venous thromboembolism, with the increased risk becoming evident during the first year of use | The authors state that hormone therapy should only be considered for the prevention of fractures if other treatments are contraindicated and if the cardiovascular risks are low (the benefits of hormone therapy will generally be outweighed by the ongoing and cumulative risk of cardiovascular disease or breast cancer)
Stevenson, 2005 ^13^ | To establish the clinical effectiveness and cost-effectiveness of alendronate, etidronate, risedronate, raloxifine, or teriparatide for the prevention and treatment of osteoporosis and the prevention of osteoporotic fractures in postmenopausal women. | Up to 2002 | Interventions- bisphosphonates: alendronate, etidronate and risedronate- serms: raloxifene- teriparatide [recombinant human pth (1–34)]• comparators- vitamin D- calcitriol (a vitamin 1 alph-hydroxylated derivative)- pharmacological doses of calcium- estrogens (opposed and unopposed)- exercise- placebo- no treatment• Outcome measures: vertebral or non-vertebral fracture, associated effects, quality of life related to the study intervention, continuance and compliance.• Study design: RCTs; trials were accepted as RCTs if the allocation of subjects to treatment groups was described by the authors as either randomized or double-blind. | Not tabulated | 90 RCTs | Women with primary osteoporosis who were at least 6 months postmenopausal | Dosages: 1. alendronate-1–40 mg per day 2. etidronate- 200 and 400 mg per day 3. risedronate-2.5 and 5 mg per day 4. raloxifine-60 and 120 mg 5. teriparatide-20,25 and 40 ug per day duration: maximum total length of treatment with teriparatide should be 18 months; the length of treatment with the other interventions is not specified | Of the five interventions, only raloxifene appeared to reduce the risk of vertebral fracture in postmenopausal women unselected for low bone mineral density (bmd). However, as the full data have not been made public, there is some uncertainty regarding this result. None of the five interventions has been shown to reduce the risk of non-vertebral fracture in women unselected for low bmd. All of the proposed interventions provided gains in qalys compared with no treatment in women with sufficient calcium and vitamin D intakes. The size of the qaly gain for each intervention was strongly related to the age of the patient. the estimated costs varied widely for the interventions. these net costs were markedly different by age, with some interventions becoming cost-saving at higher age ranges in patients with a prior fracture. | | Alendronate : one third of alendronate users reported gastrointestinal adverse events etidronate : has been associated with gastrointestinal adverse events risedronate : overall distribution of adverse events and of adverse upper gastrointestinal events, was comparable in the intervention and placebo groups raloxifene : three fold increase risk of venous thromboembolism ; higher incidence of hot flashes; arthalgia, dizziness, leg cramps, influenza like syndrome, endometrial cavity fluid, peripheral edema, and worsening of diabetes are more common teriparatide : nausea, headache mild discomfort at injection site
Boonen, 2005 ^14^ | To compare the effects of alendronate, risedronate, raloxifene, strontium, ibandronate, and calcitonin on the risk of nonvertebral fractures in intention-to-treat studies of at least 3 years duration | 1966 to March 2004 | Phase III RCTs of osteoporosis treatments of at least 3 years duration that measured radiographically confirmed nonvertebral fractures in intention to treat populations measuring incidence of new fractures by individual patient; Interventions: Bisphosphonates: alendronate, risedronate, ibandronate; SERM: raloxifene; Other: strontium, calcitonin, placebo; Outcome measure: radiographically verified nonvertebral fracture; Meta-analysis performed only on alendronate and risedronate trials | 35,984 | 11 RCTs, 3 each for alendronate and risedronate | Gender not specified, average age 69 yrs | Not described | Significant reductions in NVF found in only three trials: two of risedronate and one of strontium. However analysis of the pooled data for alendronate and risedronate showed significant reductions in the RR for NVF for both | | Not examined | Excluded studies shorter than 3 years or that did not carry out ITT analysis, stating that such studies were not valid
Nguyen, 2006 ^15^ | To quantitatively assess the effects of bisphosphonates on hip fracture | 1966 to March 2004 | RCTs of the following interventions: Alendronate, etidronate, risedronate, clodronate, placebo; Outcomes measured: BMD change, hip fracture incidence | 18,667 | 12 RCTs: 6 for alendronate, 2 etidronate, 3 risedronate, 1 clodronate | Women with postmenopausal osteoporosis or low BMD | Dosages: 1. Cycles of Etidronate 400 mg/d×2 wks, no drug ×13 wks × 10 cycles; 2. Etidronate 400mg/d × 14d, Ca only for 74 d; 3. Alendronate: 5, 10, 20 mg/d×2 years or 20mg/d followed by 5 mg/d; 4, 5. Alendronate 5 mg/d×2years followed by 10 mg/d; 6. Alend | Only two trials showed significant treatment effect: one for alendronate and 1 for risedronate; no pooled trials for a single drug showed significant effect; pooling of all studies showed significant effect. Alendronate appeared most effective of the 4 drugs. | | Not examined | Study examined fracture cases as per 1000 patients at risk rather than as patient years at risk
Sawka, 2005 ^16^ | To assess the efficacy of alendronate for fracture prevention in men with osteoporosis | Up to May 2004 | RCTs and CCTs comparing alendronate to calcium and/or vitamin D or no treatment and enrolling at least 50% men | 375 | 2 RCTs | Men with LBD or with a history of prevalent fractures due to hypogonadism, as defined by T-score | Dosages: 1. Alendronate 10 mg +500 mg Ca+400–450 IU Vitamin D vs. Ca + Vit D × 2 yrs; 2. Alendronate 10 mg+ 500 mg Ca vs. Ca + 1 mcg alfacalcidiol × 3 yrs | Significant reductions in risk (OR) for vertebral fractures but data insufficient to determine effect on nonvertebral fractures. | | Not examined | Results of the male trials were pooled using Bayesian random effx models incorporating prior information of antifracture efficacy from meta-analyses of women; Pooled results reported as Odds Ratios.
Miller, 2005 ^17^ | To assess the safety and efficacy of risedronate in patients with reduced renal function | Trials conducted 1993-1998 | Phase III RCTs comparing daily administration of risedronate to placebo for the treatment of patients with osteoporosis, excluding one trial that administered estrogen with risedronate and one that focused on Pagets | 8,996 | 9 RCTs | Patients with postmenopausal or glucocorticoid-induced osteoporosis and renal impairment (91%) | Dosage: 5 mg/d risedronate | Incidence of adverse events was similar within and between treatment groups. Most common urinary- and renal-function related event was urinary tract infection. Mean serum creatine did not differ from placebo. Changes in serum Ca and P were not considered clinically meaningful. Mean % increase in LS, femoral neck, and trochanter BMD greater in risedronate group. Incidence of new vertebral fractures was significantly lower in the risedronate group. | Mild (48%), moderate (45%), severe renal impairment (7%): No between-subgroup differences were seen except incidence of new fractures in the placebo group increased with severity of renal impairment | Primary purpose of analysis was to evaluate safety, as defined by incidence of overall, urinary-, and renal-function-related, specific renal-function related adverse events, and change from baseline in serum creatinine, calcium, and phosphorus. No differences were seen in safety between placebo and risedronate; no subgroup differences. | Renal impairment defined as estimated creatinine clearance less than 80 ml/min
Palmer, 2006 ^18^ | To assess the efficacy of agents for prevention of bone disease in kidney transplant patients | 1966 to August 2004 | RCTs and quasi-RCTs with predictable treatment allocation method assessing options for bone disease treatment (actually prevention) following kidney transplantation | 1,209 | 23 trials (2 for calcitonin) | Kidney transplant recipients | 1. Calcitonin intranasal 100 IU bd + Ca × 14 days followed by 75 days w/out treatment; 2. calcitonin 200 IU/d × 12 mos; remaining trials tested various bisphosphonates and Vitamin D but none included in a meta-analysis | Calcitonin had no significant effect on fracture risk; calcitonin significantly improved LS BMD but not FN BMD (via DXA). | | Calcitonin did not increase risk for all-cause mortality or graft loss and did not affect plasma creatinine
Seeman, 2006 ^19^ | To assess the efficacy of raloxifene for prevention of vertebral fractures among postmenopausal women | 1966 to February 2005 | RCTs at least 1 year in duration, with radiographically verifiable vertebral fracture data at baseline and subsequently | 8,282 | 5 trials | Postmenopausal women with or at risk for osteoporosis | 1 and 2. 60 or 120 mg/d raloxifene × 3 yrs; 3. 60 or 150 mg/d × 3 years; 4 and 5. 60 or 120 mg/d × 1 yr | Raloxifene at all 3 doses consistently reduced the risk of vertebral fracture. | Raloxifene at 120 or 150 mg/d resulted in a slightly greater reduction in risk than raloxifene at 60 mg/d. | Not examined | Intent to treat analysis; Ettinger distinguished women with prior vertebral fractures from those without, finding a slightly greater effect of raloxifene in the women without prior fractures at 60 mg but not at 120 mg. Authors had access to all original patient data so did not need to rely on summary statistics.
Richy, 2004 ^20^ | To assess the efficacy of two different vitamin D analogs in preserving bone mineral density and decreasing fracture rate in patients with primary or GC-induced osteoporosis | Jan 1985–July 2002 | RCTs of alphacalcidol or calcitriol with at least 6 months follow-up | 1,918 | 13 RCTs | Men or women with primary osteoporosis or individuals with glucocorticoid-induced osteoporosis | Calcitriol: 0.5–1 mcg/d + 0–1g Ca/d; Alphacalcidol: 0.5–1.0 mcg/d + 0–1 g Ca/d; Duration: 6–36 mos | Both analogs reduced the risk of overall fracture rate, vertebral fracture rate, and nonvertebral fracture rate. Calcitriol had similar efficacy to alphacalcidol but no study tested them head to head. | CS-induced vs. primary osteoporosis: Prevention of fracture in patients with GC-induced osteoporosis did not reach significance; high vs low quality studies showed similar decreases in risk; non vertebral fractures showed a similar decrease in risk to vertebral fractures; women and men showed similar decreases in risk | Not examined
Richy, 2005 ^21^ | To assess the efficacy of vitamin D analogs and native vitamin D for prevention of bone loss and fractures in patients with osteoporosis | 1985-2003 | RCTs of at least 6 months duration | 13,102 | 21 RCTs | Pre- or postmenopausal women or men age 50 and over or patients with a condition requiring GC at a dose equivalent of greater than 10 mEq prednisone/d | Native vitamin D: 300–7142 IU/d; alfacalcidol: 0.5–1.0 mcg/d; 0.25–0.62 mcg calcitriol/d; Duration: 6–36 mos. | Findings were expressed as fracture rate difference (RD); In patients with primary osteoporosis, native vitamin D and both analogs showed a significant RD compared with placebo at 24 and 36 mos. RD for analogues was significantly greater than for native vitamin D but there were no head-to-head comparisons. | In patients with GC-induced osteoporosis, no significant fracture prevention was seen with native vitamin D or analogs; however, a single head-to-head comparison of alfacalcidol and native vitamin D showed a significant RD in favor of alfacalcidol | Not examined
de Nijs, 2004 ^22^ | To assess the effect of active vitamin D analogs on prevention and treatment of GC-induced osteoporosis and to compare with bisphosphonates | 1966-2003 | RCTs, randomized open-label studies, 1 non-randomized open label study | | 1 RCT, 3 open-label randomized trials, 1 open-label non-randomized trial | Adults taking glucocorticoids | Alfacalcidol 1mcg/d vs. etidronate 400mg/d; calcitriol 0.25–0.5 mcg/d vs. pamidronate IV 0.5 mg/kg every 3 mos.; calcitriol 0.5 mcg/d vs. etidronate 400 mg/d; alfacalcidol 1 mcg/d vs. Ibandronate IV 2 mg every 3rd mo.; calcitriol 0.5–0.75mcg/d vs. alendro | Active vitamin D metabolites were less effective in reducing risk for vertebral fractures than bisphosphonates. | | Not reported | Remainder of studies analyzed compared vitamin D metabolites to combination of placebo, active vitamin D, and no treatment
Blair 2000 ^23^ | To review the use of bisphosphonates in the prevention and treatment of GC-induced OP | Not specified | RCTs of adults using bisphosphonates in which central DEXA used to measure BMD | 1,711 | 13 RCTs | Adults using bisphosphonates | Alendronate: 5–10 mg/d with 500–1000 mg Ca and 250–500 mcg/d vit D, 1 year; Clondronate: 800, 1600, 2400 mg/d × 1 yr; Etidronate: cyclical 400mg/d×2 weeks then 500 mg Ca/d or 97 mg Ca + 400 mcg/d vit D ×11–13 weeks × 1–2yr Risedronate: 2.5–5 mg/d alone or | 10 of 13 studies showed increased lumbar spine BMD but few studies showed positive effects on the femoral neck or femoral trochanter. 9 studies addressed fracture risk; only 1 study found a significant improvement in vertebral fracture risk | Six studies addressed possible differences in effects based on sex and menopausal status: Postmenopausal women seemed to derive greater benefit from treatment. | 20% of dropouts due to adverse events of which 78% deemed unrelated to study medication; no significant difference between treatment and placebo; only 1 study found a trend toward increased GI complaint with increasing alendronate dose
Wallach 2000 ^24^ | To examine the effects of risedronate treatment on GC-induced OP by combining the results of two RCTs | Not specified or relevant | Two RCTs of adults 18–85 yrs, receiving moderate to high doses of GC therapy, and expecting to be on GC for at least a year | | 2 RCTs | Adults 18–85 yrs, receiving moderate to high doses of GC therapy for a variety of conditions; in North America, participants had to have been on GC 3 months or less; in Europe, participants had to have been on GC for at least 6 mos. | 2.5–5 mg/d risedronate × 12 months or placebo. Prevention study: all pts received 500 mg Ca/d; in the Treatment study, all patients received 1000mg Ca/d and 400 IU vitamin D/d. | Outcomes included DXA-assessed lumbar spine, femoral neck, femoral trochanter, distal radius, and midshaft radius BMD (baseline, 6, and 12 mos.); serum bone-specific alkaline phosphatase and bone resorption adjusted for creatine excretion; radiographic evidence of vertebral fracture. Risedronate 5mg/d increased mean LS BMD from baseline (placebo group decreased from baseline) and either increased or maintained BMD at all other sites (compared with a decrease in placebo groups). Difference in BMD between treated and placebo group was significant at all sites. 5 mg risedronate also reduced vertebral fracture by a significant 70% cf. placebo. | Risedronate was efficacious in both men and women, irrespective of underlying disease or duration of CS therapy. | Safety profile was favorable. Upper GI adverse event rates were similar for treated and placebo groups.
Watts, 2003 ^25^ | To assess the efficacy of risedronate in preventing new vertebral fractures in high-risk postmenopausal women | Not specified or relevant | Two parallel RCTs of postmenopausal osteoporotic women treated with risedronate: VERT MN and VERT NA | | 2 RCTs | Postmenopausal women (at least 5 years PM) 85 yrs or younger, with two or more radiographically confirmed vertebral fractures or one vertebral fracture ad low lumbar spine BMD or BMD of =0.94 g/cm2 (T score=-2) | 2.5–5 mg/d risedronate or placebo; all patients received 1000mg Ca/d and up to 500 IU vitamin D/d if baseline serum vitamin D<40 nmol/l. | Risk of new vertebral fractures in the 5mg/d group decreased 62% at 1 year in the pooled cohorts (RR 0.38; 95% CI 0.25, 0.56); 61% in VERT-MN and 65% in VERT-NA; risedronate also reduced incidence of multiple new vertebral fractures (3.1% in controls vs. 0.3% in 5 mg treated;90% decrease in risk; rr, 0.10, 95% CI, 0.04, 0.26) | Similar decreases in new fracture risk were seen in women under 70 (7% vs. 2.6%, or 64% reduction (rr, 0.36, 95% CI 0.19, 0.68) and women over 70 (10.8% vs. 4.4%, or 62% reduction (rr, 0.38, 95% CI 0.23, 0.64). Risedronate also decreased the fracture risk in women with at least two existing fractures at baseline (12% vs. 4.1%, or 68% reduction; rr, 0.32; 95%CI, 0.20, 0.49) and in women with low BMD in the femoral neck (12.8% vs. 5.6% or 60% reduction; rr, 0.40, 95% CI, 0.23, 0.67) and women with low lumbar spine BMD (6.9% vs. 3.7% or 48% reduction, rr, 0.52, 95% CI, 0.29, 0.93). | Not reported here.
Torgerson, 2001 ^26^ | To determine if HRT reduced nonvertebral fractures. | RCTs. 1997-2000 plus older systematic reviews. | RCT of HRT ≥ 12 months, including unblinded trials. | 8,774 | 22 RCTs | Women—post menopausal or hysterectomy. | Estrogens (transdermal estradiol-.1mg,50ug; oral estradiol-1mg,2mg; oral conjugated estrogens-.625mg,.3mg) | HRT associated with reduction in all nonvertebral fractures (RR 0.73, 95% CI 0.56–0.94) | HRT was more effective in trials of women under age 60 (RR 0.67, 95% CI 0.46–0.98) than in trials of women age 60 and above (RR 0.88, 95% CI 0.71–1.08) | Not reported.

### Reference List for Evidence Table C4

1 Torgerson DJ, Bell-Syer SE. (2001). Hormone replacement therapy and prevention of vertebral fractures: a meta-analysis of randomised trials. BMC Musculoskelet Disord.
2 Cranney A, Guyatt G, Krolicki N, et al. (2001). A meta-analysis of etidronate for the treatment of postmenopausal osteoporosis. Osteoporos Int.
3 Wells G, Tugwell P, Shea B, et al. (2002). Meta-analyses of therapies for postmenopausal osteoporosis. V. Meta-analysis of the efficacy of hormone replacement therapy in treating and preventing osteoporosis in postmenopausal women. Endocr Rev.
4 Cranney A, Tugwell P, Adachi J, et al. (2002). Meta-analyses of therapies for postmenopausal osteoporosis. III. Meta-analysis of risedronate for the treatment of postmenopausal osteoporosis. Endocr Rev.
5 Cranney A, Wells G, Willan A, et al. (2002). Meta-analyses of therapies for postmenopausal osteoporosis. II. Meta-analysis of alendronate for the treatment of postmenopausal women. Endocr Rev.
6 Cranney A, Tugwell P, Zytaruk N, et al. (2002). Meta-analyses of therapies for postmenopausal osteoporosis. VI. Meta-analysis of calcitonin for the treatment of postmenopausal osteoporosis. Endocr Rev.
7 Karpf DB, Shapiro DR, Seeman E, et al. (1997). Prevention of nonvertebral fractures by alendronate. A meta-analysis. Alendronate Osteoporosis Treatment Study Groups. JAMA.
8 Papapoulos SE, Quandt SA, Liberman UA, et al. (2005). Meta-analysis of the efficacy of alendronate for the prevention of hip fractures in postmenopausal women. Osteoporos Int.
9 Cranney A, Adachi JD, Homik JJEH, et al. Calcitonin for preventing and treating corticosteroid-induced osteoporosis. Cochrane Database of Systematic Reviews 2005;(3)
10 Cranney A, Waldegger L, Zytaruk N, et al. Risedronate for the prevention and treatment of postmenopausal osteoporosis. Cochrane Database Syst Rev 2003;(4):CD004523.
11 Cranney A, Welch V, Adachi JD, et al. Etidronate for treating and preventing postmenopausal osteoporosis. Cochrane Database of Systematic Reviews 2005;(3)
12 Farquhar CM, Marjoribanks J, Lethaby A, et al. Long term hormone therapy for perimenopausal and postmenopausal women. Cochrane Database of Systematic Reviews 2005;(3)
13 Stevenson M, Lloyd Jones M, De Nigris E, et al. (2005). A systematic review and economic evaluation of alendronate, etidronate, risedronate, raloxifene and teriparatide for the prevention and treatment of postmenopausal osteoporosis. Health Technol Assess.
14 Boonen S, Laan RF, Barton IP, et al. (2005). Effect of osteoporosis treatments on risk of non-vertebral fractures: review and meta-analysis of intention-to-treat studies. Osteoporos Int.
15 Nguyen ND, Eisman JA, Nguyen TV. (2006). Anti-hip fracture efficacy of biophosphonates: a Bayesian analysis of clinical trials. J Bone Miner Res.
16 Sawka AM, Papaioannou A, Adachi JD, et al. (2005). Does alendronate reduce the risk of fracture in men? A meta-analysis incorporating prior knowledge of anti-fracture efficacy in women. BMC Musculoskelet Disord.
17 Miller PD, Roux C, Boonen S, et al. (2005). Safety and efficacy of risedronate in patients with age-related reduced renal function as estimated by the Cockcroft and Gault method: a pooled analysis of nine clinical trials. J Bone Miner Res.
18 Palmer S, McGregor DO, Strippoli GF. Interventions for preventing bone disease in kidney transplant recipients. Cochrane Database Syst Rev 2005;(2):CD005015.
19 Seeman E, Crans GG, Diez-Perez A, et al. (2006). Anti-vertebral fracture efficacy of raloxifene: a meta-analysis. Osteoporos Int.
20 Richy F, Ethgen O, Bruyere O, et al. (2004). Efficacy of alphacalcidol and calcitriol in primary and corticosteroid-induced osteoporosis: a meta-analysis of their effects on bone mineral density and fracture rate. Osteoporos Int.
21 Richy F, Schacht E, Bruyere O, et al. (2005). Vitamin D analogs versus native vitamin D in preventing bone loss and osteoporosis-related fractures: a comparative meta-analysis. Calcif Tissue Int.
22 de Nijs RN, Jacobs JW, Algra A, et al. (2004). Prevention and treatment of glucocorticoid-induced osteoporosis with active vitamin D3 analogues: a review with meta-analysis of randomized controlled trials including organ transplantation studies. Osteoporos Int.
23 Blair MM, Carson DS, Barrington R. (2000). Bisphosphonates in the prevention and treatment of glucocorticoid-induced osteoporosis. J Fam Pract.
24 Wallach S, Cohen S, Reid DM, et al. (2000). Effects of risedronate treatment on bone density and vertebral fracture in patients on corticosteroid therapy. Calcif Tissue Int.
25 Watts NB, Josse RG, Hamdy RC, et al. (2003). Risedronate prevents new vertebral fractures in postmenopausal women at high risk. J Clin Endocrinol Metab.
26 Torgerson DJ, Bell-Syer SE. (2001). Hormone replacement therapy and prevention of nonvertebral fractures: a meta-analysis of randomized trials. JAMA.

## Evidence Table C5. Systematic Reviews Quality Assessment Evidence Table - Internal Validity

Evidence Table C5. Systematic Reviews Quality Assessment Evidence Table - Internal Validity

Author, Year | Comprehensive sources? | Literature search strategy specified? | Important studies missing? | Explicit eligibility criteria? | Adequate detail about primary studies? | Standard method of appraisal of studies?
Torgerson, 2001 ^1^ | Yes | Yes | No | Yes | Yes | Yes
Cranney, 2001 ^2^ | Yes | Yes | No | Yes | Yes | Yes
Wells, 2002 ^3^ | Yes | Yes | No | Yes | Yes | Yes
Cranney, 2002 ^4^ | Yes | Yes | No | Yes | Yes | Yes
Cranney, 2002 ^5^ | Yes | Yes | No | Yes | Yes | Yes
Cranney, 2002 ^6^ | Yes | Yes | No | Yes | Yes | Yes
Karpf, 1997 ^7^ | Not reported | No | No | Yes | Yes | No
Papapoulos, 2004 ^8^ | Yes | Yes | No | Yes | Yes | Yes
Cranney, 2000 ^9^ | Yes | Yes | No | Yes | Yes | Yes
Cranney, 2003 ^10^ | Yes | Yes | No | Yes | Yes | Yes
Cranney, 2001 ^11^ | Yes | Yes | No | Yes | Yes | Yes
Farquhar, 2005 ^12^ | Yes | Yes | No | Yes | Yes | Yes
Stevenson, 2005 ^13^ | Yes | Yes | No | Yes | Yes | Yes
Boonen, 2005 ^14^ | Yes | Yes | No | Yes | No dose information | Yes
Nguyen, 2006 ^15^ | Only English; only peer-reviewed | Yes | No | Yes | Yes | Yes
Sawka, 2005 ^16^ | Yes | Yes | No | YES | Yes | Yes
Miller, 2005 ^17^ | Yes | No | No | Yes | Yes | No
Palmer, 2006 ^18^ | Yes | Yes | No | Yes | Yes | Yes
Seeman, 2006 ^19^ | Yes | Yes | No | Yes | Yes | Yes
Richy, 2004 ^20^ | Yes | Yes | No | Yes | Yes | Yes
Richy, 2005 ^21^ | Yes | Yes | No | Yes | Yes | Yes
de Nijs, 2004 ^22^ | Yes | Yes | No | Yes | Yes | Yes
Blair, 2000 ^23^ | Yes | Yes | No | Yes | Yes | Yes
Wallach, 2000 ^24^ | No | Not applicable | N/A | Yes | Yes | N/A
Watts, 2003 ^25^ | No | Not applicable | N/A | Yes | Yes | N/A
Torgerson, 2001 ^26^ | Yes | Yes | No | Yes | Yes | Yes

### Reference List for Evidence Table C5

1 Torgerson DJ, Bell-Syer SE. (2001). Hormone replacement therapy and prevention of vertebral fractures: a meta-analysis of randomised trials. BMC Musculoskelet Disord.
2 Cranney A, Guyatt G, Krolicki N, et al. (2001). A meta-analysis of etidronate for the treatment of postmenopausal osteoporosis. Osteoporos Int.
3 Wells G, Tugwell P, Shea B, et al. (2002). Meta-analyses of therapies for postmenopausal osteoporosis. V. Meta-analysis of the efficacy of hormone replacement therapy in treating and preventing osteoporosis in postmenopausal women. Endocr Rev.
4 Cranney A, Tugwell P, Adachi J, et al. (2002). Meta-analyses of therapies for postmenopausal osteoporosis. III. Meta-analysis of risedronate for the treatment of postmenopausal osteoporosis. Endocr Rev.
5 Cranney A, Wells G, Willan A, et al. (2002). Meta-analyses of therapies for postmenopausal osteoporosis. II. Meta-analysis of alendronate for the treatment of postmenopausal women. Endocr Rev.
6 Cranney A, Tugwell P, Zytaruk N, et al. (2002). Meta-analyses of therapies for postmenopausal osteoporosis. VI. Meta-analysis of calcitonin for the treatment of postmenopausal osteoporosis. Endocr Rev.
7 Karpf DB, Shapiro DR, Seeman E, et al. (1997). Prevention of nonvertebral fractures by alendronate. A meta-analysis. Alendronate Osteoporosis Treatment Study Groups. JAMA.
8 Papapoulos SE, Quandt SA, Liberman UA, et al. (2005). Meta-analysis of the efficacy of alendronate for the prevention of hip fractures in postmenopausal women. Osteoporos Int.
9 Cranney A, Adachi JD, Homik JJEH, et al. Calcitonin for preventing and treating corticosteroid-induced osteoporosis. Cochrane Database of Systematic Reviews 2005;(3)
10 Cranney A, Waldegger L, Zytaruk N, et al. Risedronate for the prevention and treatment of postmenopausal osteoporosis. Cochrane Database Syst Rev 2003;(4):CD004523.
11 Cranney A, Welch V, Adachi JD, et al. Etidronate for treating and preventing postmenopausal osteoporosis. Cochrane Database of Systematic Reviews 2005;(3)
12 Farquhar CM, Marjoribanks J, Lethaby A, et al. Long term hormone therapy for perimenopausal and postmenopausal women. Cochrane Database of Systematic Reviews 2005;(3)
13 Stevenson M, Lloyd Jones M, De Nigris E, et al. (2005). A systematic review and economic evaluation of alendronate, etidronate, risedronate, raloxifene and teriparatide for the prevention and treatment of postmenopausal osteoporosis. Health Technol Assess.
14 Boonen S, Laan RF, Barton IP, et al. (2005). Effect of osteoporosis treatments on risk of non-vertebral fractures: review and meta-analysis of intention-to-treat studies. Osteoporos Int.
15 Nguyen ND, Eisman JA, Nguyen TV. (2006). Anti-hip fracture efficacy of biophosphonates: a Bayesian analysis of clinical trials. J Bone Miner Res.
16 Sawka AM, Papaioannou A, Adachi JD, et al. (2005). Does alendronate reduce the risk of fracture in men? A meta-analysis incorporating prior knowledge of anti-fracture efficacy in women. BMC Musculoskelet Disord.
17 Miller PD, Roux C, Boonen S, et al. (2005). Safety and efficacy of risedronate in patients with age-related reduced renal function as estimated by the Cockcroft and Gault method: a pooled analysis of nine clinical trials. J Bone Miner Res.
18 Palmer S, McGregor DO, Strippoli GF. Interventions for preventing bone disease in kidney transplant recipients. Cochrane Database Syst Rev 2005;(2):CD005015.
19 Seeman E, Crans GG, Diez-Perez A, et al. (2006). Anti-vertebral fracture efficacy of raloxifene: a meta-analysis. Osteoporos Int.
20 Richy F, Ethgen O, Bruyere O, et al. (2004). Efficacy of alphacalcidol and calcitriol in primary and corticosteroid-induced osteoporosis: a meta-analysis of their effects on bone mineral density and fracture rate. Osteoporos Int.
21 Richy F, Schacht E, Bruyere O, et al. (2005). Vitamin D analogs versus native vitamin D in preventing bone loss and osteoporosis-related fractures: a comparative meta-analysis. Calcif Tissue Int.
22 de Nijs RN, Jacobs JW, Algra A, et al. (2004). Prevention and treatment of glucocorticoid-induced osteoporosis with active vitamin D3 analogues: a review with meta-analysis of randomized controlled trials including organ transplantation studies. Osteoporos Int.
23 Blair MM, Carson DS, Barrington R. (2000). Bisphosphonates in the prevention and treatment of glucocorticoid-induced osteoporosis. J Fam Pract.
24 Wallach S, Cohen S, Reid DM, et al. (2000). Effects of risedronate treatment on bone density and vertebral fracture in patients on corticosteroid therapy. Calcif Tissue Int.
25 Watts NB, Josse RG, Hamdy RC, et al. (2003). Risedronate prevents new vertebral fractures in postmenopausal women at high risk. J Clin Endocrinol Metab.
26 Torgerson DJ, Bell-Syer SE. (2001). Hormone replacement therapy and prevention of nonvertebral fractures: a meta-analysis of randomized trials. JAMA.

## Evidence Table C6. Systematic Reviews Quality Assessment Evidence Table - External Validity

Evidence Table C6. Systematic Reviews Quality Assessment Evidence Table - External Validity

Author, Year | Study results synthesized? | (1) Exclusion criteria: All trials except: | (2) Relevant to a key question? | (3) Funding source and role of funder
Cranney, 2000 ^1^ | Yes | RCT that used calcitonin for the prevention or treatment of steroid induced osteoporosis; men or women over age 18 with any underlying disease requiring therapy with steroids; randomized allocation of patients into treatment groups; adequate description of the intervention medications in terms of dosage scheduling and administration | Yes | External sources of support-no courses of support supplied; Internal sources of support-Loeb Research Institute, Clinical Epidemiology Unit Canada.
Cranney, 2001 ^2^ | Yes | See Wells, 2002 for eligibility criteria; additional exclusion criteria: * didn't include data from the HRT arm or combined HRT/etibronate arm of Wimalawansa 1995 & 1998. | Yes | Not reported
Cranney, 2001 ^3^ | Yes | INCLUDED Trials that randomized postmenopausal women to etidronate or an alternative (placebo or calcium and /or vitamin D) and measured bone density for at least 1 year | Yes | Merck provided an unrestricted educational grant Canada ; Proctor & Gamble contributed a small unrestricted educational grant Canada; Ottawa Health Research Institute- Clinical Epidemiology Unit, Ottawa Hospital, Ottawa, Ontario Canada; University of Ottawa- Institute of Population Health Canada
Cranney, 2002 ^4^ | Yes | INCLUDED (1) Randomized, placebo-controlled trials of risedronate for osteoporosis in postmenopausal women defined as greater than 6 months postmenopausal); 2)follow up of at least one year; and 3)fracture incidence or bone mineral density data available | Yes | Merck provided partial funding.
Cranney, 2002 ^5^ | Yes | INCLUDED (1) RCTs comparing postmenopausal women receiving alendronate to those not receiving alendronate with follow up of at least 1 year; and 2)fracture incidence, or BMD data | Yes | Work was supported in part through educational grants from Merck, Inc.
Cranney, 2002 ^6^ | Yes | INCLUDED (1) RCTs of at least 1-yr duration, comparing calcitonin therapy vs. placebo or calcium and/or vitamin D; 2) outcomes included BMD or fracture incidence; and 3) participants were postmenopausal women | Yes | Not reported
Cranney, 2003 ^7^ | Yes | INCLUDED Studies which randomized women to risedronate or an alternative (placebo or calcium and/or vit. D) and measured BMD for at least 1yr | Yes | A. Cranney was supported by a Arthritis Society Junior Research Scholar and A. Papaioannou is a Ministry of Health Clinician Scientist Canada; Ottawa Health Research Institute, Clinical Epidemiology Canada; Queen's University, Department of Medicine Canada
Farquahr, 2005 ^8^ | Yes | Randomized double blind trials of hormone therapy (estrogens with or without progestogens) versus placebo, taken for at least one year by perimenopausal or postmenopausal women additional exclusion criteria: *studies with co interventions that might effect the outcomes being measured or which used topical vaginal hormone therapy creams, topical hormone therapy tablets, or hormone therapy rings | Yes | External sources of support - no sources of support supplied; internal sources of support - University of Aukland New Zealand
Karpf, 1997 ^9^ | Yes | INCLUDED all postmenopausal women randomized to treatment with placebo or alendronate at a dose higher than 1mg per day for at least 2 year that evaluated the efficacy of treatment | Yes | Published data & data on file at Merck Research Laboratories; this study was supported in part by Merck Research Laboratories
Papapoulos, 2004 ^10^ | Yes | Aimed to include all RCT with alendronate in postmenopausal women with a t-score of 2.0 or less, or w/ a vertebral # in which there were sufficient data to evaluate the relative risk; specifically there was at least one patient in each treatment group that experienced a hip fracture | Yes | Not reported
Stevenson, 2005 ^11^ | Yes | Studies were excluded if they included participants with secondary osteoporosis (e.g. related to therapy with corticosteroids), or drew their participants exclusively from patients with specific diseases known to effect fracture rates (e.g. parkinson's disease) - only published studies (including those only available in abstract form) were included - it was possible only to include studies published in English, French, German, Italian, or Spanish. This led to an exclusion of one possibly relevant study published only in Japanese | Yes | Commissioned and funded by health technology assessment program on behalf of NICE (National Institute for Health and Clinical Excellence), United Kingdom
Torgerson, 2001 ^12^ | Yes | INCLUDED RCT of HRT where women had been randomized to at least 12 mon. of HRT or to no HRT. | Yes | Review partly funded from an unrestricted educational grant from Wyeth Pharmaceuticals
Wells, 2002 ^13^ | Yes | INCLUDED 1) RCT in postmenopausal women that compared an HRT intervention (estrogen used alone or estrogen opposed by progestin) with a placebo (2)HRT could be given in conjunction with a calcium and vitamin D, provided the other group received the same (3)results had to be reported with a follow up of at least one year on one or more of the outcomes of interest (4) both prevention and rx trials were accepted (rx referring to studies that included women w/ prevalent #'s at baseline) | Yes | Not reported
Boonen, 2005 ^14^ | Yes | Studies, including RCTs, of less than three years duration; studies that did not use radiographic verification | Yes | Fund for Scientific Research, Flanders Belgium, Grant # G.0171.03N
Nguyen, 2006 ^15^ | Yes | Duration of follow up less than 12 months; papers in languages other than English; papers not published in peer reviewed journals | Yes | Not Reported
Sawka, 2005 ^16^ | Yes | Trials with fewer than 50% men; trials that included patients with bone or mineral disorders other than primary osteoporosis, with the exception of osteoporosis secondary to hypogonadism; trials in which controls received active anti-osteoporotic therapy; Duration of followup less than 1 year | Yes | Not Reported
Miller, 2005 ^17^ | Yes | One trial in which participants received risedronate + estrogen; one trial that focused on Paget's Disease | Yes | Proctor and Gamble Pharmaceuticals and sanofi-aventis
Seeman, 2006 ^18^ | Yes | Trials of less than one year, trials without radiographic verification of fracture and baseline measures | Yes | Eli Lilly
Richy, 2004 ^19^ | Yes | Trials of less than 6 months | Yes | TEVA Pharmaceutical Industries
Richy, 2005 ^20^ | Yes | Trials of less than 6 months; trials reported only in abstracts if authors failed to provide complete report after being contacted | Yes | Not Reported
de Nijs, 2004 ^21^ | Yes | Trials of nonadult patients | Yes | Dutch Health Insurance Fund Council
Blair, 2000 ^22^ | Yes | Trials of nonadult patients or patients not taking GCs; trials that did not use central DEXA to assess BMD | Yes | Not reported
Wallach, 2000 ^23^ | Yes? Pooled results of two studies | All studies except two parallel RCTs of risedronate treatment of postmenopausal women of at least 5 years duration, 85 yoa or less at high risk of fracture who had not received drugs known to affect bone metabolism and did not have conditions that would affect evaluation of spinal bone loss | Yes | Proctor and Gamble Pharmaceuticals and Aventis Pharma
Watts, 2003 ^24^ | Yes? Pooled results of two studies | All studies except two parallel RCTs of risedronate treatment of adults on GC therapy for less than 3 or more than 6 months; other exclusion criteria for trials included evidence of metabolic bone disease other than GC-induced osteoporosis, recent use of | Yes | Proctor and Gamble Pharmaceuticals and Aventis Pharma
Torgerson, 2001 ^25^ | Yes | INCLUDED: RCTs of HRT where women had been randomized to at least 12 months of HRT and no HRT. | Yes | Not reported.

### Reference List for Evidence Table C6

1 Cranney A, Adachi JD, Homik JJEH, et al. Calcitonin for preventing and treating corticosteroid-induced osteoporosis. Cochrane Database of Systematic Reviews 2005;(3)
2 Cranney A, Guyatt G, Krolicki N, et al. (2001). A meta-analysis of etidronate for the treatment of postmenopausal osteoporosis. Osteoporos Int.
3 Cranney A, Welch V, Adachi JD, et al. Etidronate for treating and preventing postmenopausal osteoporosis. Cochrane Database of Systematic Reviews 2005;(3)
4 Cranney A, Tugwell P, Adachi J, et al. (2002). Meta-analyses of therapies for postmenopausal osteoporosis. III. Meta-analysis of risedronate for the treatment of postmenopausal osteoporosis. Endocr Rev.
5 Cranney A, Wells G, Willan A, et al. (2002). Meta-analyses of therapies for postmenopausal osteoporosis. II. Meta-analysis of alendronate for the treatment of postmenopausal women. Endocr Rev.
6 Cranney A, Tugwell P, Zytaruk N, et al. (2002). Meta-analyses of therapies for postmenopausal osteoporosis. VI. Meta-analysis of calcitonin for the treatment of postmenopausal osteoporosis. Endocr Rev.
7 Cranney A, Waldegger L, Zytaruk N, et al. Risedronate for the prevention and treatment of postmenopausal osteoporosis. Cochrane Database Syst Rev 2003;(4):CD004523.
8 Farquhar CM, Marjoribanks J, Lethaby A, et al. Long term hormone therapy for perimenopausal and postmenopausal women. Cochrane Database of Systematic Reviews 2005;(3)
9 Karpf DB, Shapiro DR, Seeman E, et al. (1997). Prevention of nonvertebral fractures by alendronate. A meta-analysis. Alendronate Osteoporosis Treatment Study Groups. JAMA.
10 Papapoulos SE, Quandt SA, Liberman UA, et al. (2005). Meta-analysis of the efficacy of alendronate for the prevention of hip fractures in postmenopausal women. Osteoporos Int.
11 Stevenson M, Lloyd Jones M, De Nigris E, et al. (2005). A systematic review and economic evaluation of alendronate, etidronate, risedronate, raloxifene and teriparatide for the prevention and treatment of postmenopausal osteoporosis. Health Technol Assess.
12 Torgerson DJ, Bell-Syer SE. (2001). Hormone replacement therapy and prevention of vertebral fractures: a meta-analysis of randomised trials. BMC Musculoskelet Disord.
13 Wells G, Tugwell P, Shea B, et al. (2002). Meta-analyses of therapies for postmenopausal osteoporosis. V. Meta-analysis of the efficacy of hormone replacement therapy in treating and preventing osteoporosis in postmenopausal women. Endocr Rev.
14 Boonen S, Laan RF, Barton IP, et al. (2005). Effect of osteoporosis treatments on risk of non-vertebral fractures: review and meta-analysis of intention-to-treat studies. Osteoporos Int.
15 Nguyen ND, Eisman JA, Nguyen TV. (2006). Anti-hip fracture efficacy of biophosphonates: a Bayesian analysis of clinical trials. J Bone Miner Res.
16 Sawka AM, Papaioannou A, Adachi JD, et al. (2005). Does alendronate reduce the risk of fracture in men? A meta-analysis incorporating prior knowledge of anti-fracture efficacy in women. BMC Musculoskelet Disord.
17 Miller PD, Roux C, Boonen S, et al. (2005). Safety and efficacy of risedronate in patients with age-related reduced renal function as estimated by the Cockcroft and Gault method: a pooled analysis of nine clinical trials. J Bone Miner Res.
18 Seeman E, Crans GG, Diez-Perez A, et al. (2006). Anti-vertebral fracture efficacy of raloxifene: a meta-analysis. Osteoporos Int.
19 Richy F, Ethgen O, Bruyere O, et al. (2004). Efficacy of alphacalcidol and calcitriol in primary and corticosteroid-induced osteoporosis: a meta-analysis of their effects on bone mineral density and fracture rate. Osteoporos Int.
20 Richy F, Schacht E, Bruyere O, et al. (2005). Vitamin D analogs versus native vitamin D in preventing bone loss and osteoporosis-related fractures: a comparative meta-analysis. Calcif Tissue Int.
21 de Nijs RN, Jacobs JW, Algra A, et al. (2004). Prevention and treatment of glucocorticoid-induced osteoporosis with active vitamin D3 analogues: a review with meta-analysis of randomized controlled trials including organ transplantation studies. Osteoporos Int.
22 Blair MM, Carson DS, Barrington R. (2000). Bisphosphonates in the prevention and treatment of glucocorticoid-induced osteoporosis. J Fam Pract.
23 Wallach S, Cohen S, Reid DM, et al. (2000). Effects of risedronate treatment on bone density and vertebral fracture in patients on corticosteroid therapy. Calcif Tissue Int.
24 Watts NB, Josse RG, Hamdy RC, et al. (2003). Risedronate prevents new vertebral fractures in postmenopausal women at high risk. J Clin Endocrinol Metab.
25 Torgerson DJ, Bell-Syer SE. (2001). Hormone replacement therapy and prevention of nonvertebral fractures: a meta-analysis of randomized trials. JAMA.