# Appendix A Search Strategy

## Osteoporosis/Bone Mineral Density - Search Methodologies

DATABASE SEARCHED& TIME PERIOD COVERED:

PubMed - 1966-2005 - Initial search

OTHER LIMITERS:

ENGLISH

HUMAN

SEARCH STRATEGIES:

SEARCH #1a (Specified bisphosphonates)

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

alendronate* OR fosamax (860)

OR

resindronate* OR actonel (174)

OR

etidronate* OR didronel (623)

OR

ibandronate* OR boniva (93)

OR

pamidronate* OR aredia (412)

OR

zoledronic acid OR zometa (112)

OR

droloxifene* (13)

TOTAL OF ABOVE SEARCHES - DUPLICATES ELIMINATED: 1757

SEARCH #1b (Other bisphosphonates)

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

bisphosphonate*

NOT

Results of Search #1a

TOTAL NUMBER OF ITEMS: 687

SEARCH #2a (Specified SERMs)

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

raloxifene* OR evista (560)

tamoxifen* OR nolvadex OR emblon OR fentamox OR soltamox OR tamofen (697)

TOTAL OF ABOVE SEARCHES - DUPLICATES ELIMINATED: 784

SEARCH #2b (Other SERMs)

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

selective estrogen receptor modulators OR serm OR serms

NOT

Results of Search #2a

TOTAL NUMBER OF ITEMS: 186

SEARCH #3 (Calcitonin)

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

calcitonin* OR miacalcin OR calcimar OR cibacalcin

NOT

pth OR parathyroid hormone

TOTAL NUMBER OF ITEMS: 1078

SEARCH #4 (PTH)

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

pth OR parathyroid hormone

TOTAL NUMBER OF ITEMS: 3787

SEARCH #5 (Teriparatide)

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

teriparatide OR forteo

TOTAL NUMBER OF ITEMS: 182

SEARCH #6 (Exercise)

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

(exercise[mh] OR exercis*[ti] OR physical fitness OR physically fit OR physical activity)

NOT

Results of previous searches

TOTAL NUMBER OF ITEMS: 2832

SEARCH #7 (Letrozole)

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

letrozole OR femora

NOT

Results of previous searches

TOTAL NUMBER OF ITEMS: 356

SEARCH #8 (AMG 162)

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

amg162 OR amg 162

TOTAL NUMBER OF ITEMS: 2

SEARCH #9 (Ospemifene)

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

ospemifene*

TOTAL NUMBER OF ITEMS: 6

SEARCH #10 (Strontium ralenate)

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

strontium ralenate*

NOT

Results of previous searches

TOTAL NUMBER OF ITEMS: 167

SEARCH #11(Testosterone)

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

testosterone

TOTAL NUMBER OF ITEMS: 904

SEARCH #12 (Tiludronate)

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

tiludronate OR skelid

TOTAL NUMBER OF ITEMS: 38

SEARCH #13 (Toremifene)

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

toremifene*

TOTAL NUMBER OF ITEMS: 27

## Osteoporosis/Osteopenia & Therapies - Other Data Bases - Initial Searches

DATABASE:

EBM Reviews On OVID (Cochrane Database of Systematic Reviews, DARE, Controlled Trials Register, and ACP Journal Club databases)

DATE LIMITERS - None

SEARCH STRATEGY:

NOTE: “mp.” is a group field indicator in OVID. The fields searched are:

Title, Short Title, Abstract, Text Word, Keyword, Heading Word, Caption Text, MESH heading

osteoporosis or osteopenia or osteopaenia or fracture$ or bone mineral.mp.

AND

bisphosphonate$.mp. 258

alendronate$ or fosamax.mp. 294

resindronate$ or actonel.mp. 1

etidronate$ or didronel.mp. 153

ibandronate$ or boniva.mp. 35

pamidronate$ or aredia.mp. 105

zoledronic acid$ or zometa.mp. 19

selective estrogen receptor modulator$ or serm$.mp. 108

raloxifene or evista.mp. 141

tamoxifen or nolvadex or emblon or fentamox or soltamox or tamofen.mp. 80

droloxifene.mp. 1

calcitonin$ or miacalcin or calcimar or cibacalcin.mp. 311

parathyroid hormone$ or pth.mp. 366

teriparatide or forteo.mp. 26

exercis$.mp. and (calcium or vitamin d).mp. 140

ALL RECORDS WERE IMPORTED INTO PROCITE AND DUPLICATES WERE REMOVED. TOTAL NUMBER OF UNIQUE ITEMS: 1390

## Osteoporosis / Low Bone Density (Searches Performed After Draft Report Feedback)

DATABASE SEARCHED& TIME PERIOD COVERED:

PubMed - 1966-2006

OTHER LIMITERS:

ENGLISH

HUMAN

SEARCH STRATEGIES:

SEARCH #1A (Bisphosphonates & Breast Cancer)

bisphosphonate*

AND

breast neoplasms OR breast cancer[tiab]

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 41

SEARCH #1B (Bisphosphonates & Colon Cancer)

bisphosphonate*

AND

colonic neoplasms OR colon cancer[tiab]

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 5

SEARCH #1C (Bisphosphonates & Lung Cancer)

bisphosphonate*

AND

lung neoplasms OR lung cancer[tiab]

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 5

SEARCH #1D (Bisphosphonates & Osteosarcoma)

bisphosphonate*

AND

osteosarcoma*

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 2

SEARCH #1E (Bisphosphonates & Esophageal Ulcer)

bisphosphonate*

AND

(esophagus OR esophageal) AND ulcer*

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 0

SEARCH #1F(Bisphosphonates & PUBS)

bisphosphonate*

AND

perforation* OR ulcer* OR bleed*

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 7

SEARCH #1G(Bisphosphonates & Osteonecrosis)

bisphosphonate*

AND

osteonecrosis

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 29

SEARCH #2A(Alendronate & Breast Cancer)

alendronate*

AND

breast neoplasms OR breast cancer[tiab]

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 9

SEARCH #2B(Alendronate & Colon Cancer)

alendronate*

AND

colonic neoplasms OR colon cancer[tiab]

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 1

SEARCH #2C(Alendronate & Lung Cancer)

alendronate*

AND

lung neoplasms OR lung cancer[tiab]

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 2

SEARCH #2D(Alendronate & Osteosarcoma)

alendronate*

AND

osteosarcoma*

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 1

SEARCH #2E(Alendronate & Esophageal Ulcers)

alendronate*

AND

(esophagus OR esophageal) AND ulcer*

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 8

SEARCH #2F(Alendronate & PUBS)

alendronate*

AND

perforation* OR ulcer* OR bleed*

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 20

SEARCH #2G(Alendronate & Osteonecrosis)

alendronate*

AND

osteonecrosis

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 4

SEARCH #3A(Etidronate & Breast Cancer)

etidronate*

AND

breast neoplasms OR breast cancer[tiab]

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 2

SEARCH #3B(Etidronate & Colon Cancer)

etidronate*

AND

colonic neoplasms OR colon cancer[tiab]

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 1

SEARCH #3C(Etidronate & Lung Cancer)

etidronate*

AND

lung neoplasms OR lung cancer[tiab]

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 1

SEARCH #3D(Etidronate & Osteosarcoma)

etidronate*

AND

osteosarcoma*

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 0

SEARCH #3E(Etidronate & Esophageal Ulcers)

etidronate*

AND

(esophagus OR esophageal) AND ulcer*

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 4

SEARCH #3F(Etidronate & PUBS)

etidronate*

AND

perforation* OR ulcer* OR bleed*

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 9

SEARCH #3G(Etidronate & Osteonecrosis)

etidronate*

AND

osteonecrosis

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 1

SEARCH #4A(Ibandronate & Breast Cancer)

ibandronate*

AND

breast neoplasms OR breast cancer[tiab]

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 4

SEARCH #4B(Ibandronate & Colon Cancer)

ibandronate*

AND

colonic neoplasms OR colon cancer[tiab]

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 0

SEARCH #4C(Ibandronate & Lung Cancer)

ibandronate*

AND

lung neoplasms OR lung cancer[tiab]

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 0

SEARCH #4D(Ibandronate & Osteosarcoma)

ibandronate*

AND

osteosarcoma*

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 0

SEARCH #4E(Ibandronate & Esophageal Ulcers)

ibandronate*

AND

(esophagus OR esophageal) AND ulcer*

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 0

SEARCH #4F(Ibandronate & PUBS)

ibandronate*

AND

perforation* OR ulcer* OR bleed*

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 0

SEARCH #4G(Ibandronate & Osteonecrosis)

ibandronate*

AND

osteonecrosis

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 1

SEARCH #5A(Pamidronate & Breast Cancer)

pamidronate*

AND

breast neoplasms OR breast cancer[tiab]

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 23

SEARCH #5B(Pamidronate & Colon Cancer)

pamidronate*

AND

colonic neoplasms OR colon cancer[tiab]

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 0

SEARCH #5C(Pamidronate & Lung Cancer)

pamidronate*

AND

lung neoplasms OR lung cancer[tiab]

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 13

SEARCH #5D(Pamidronate & Osteosarcoma)

pamidronate*

AND

osteosarcoma*

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 1

SEARCH #5E(Pamidronate & Esophageal Ulcers)

pamidronate*

AND

(esophagus OR esophageal) AND ulcer*

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 1

SEARCH #5F(Pamidronate & PUBS)

pamidronate*

AND

perforation* OR ulcer* OR bleed*

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 5

SEARCH #5G(Pamidronate & Osteonecrosis)

pamidronate*

AND

osteonecrosis

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 10

SEARCH #6A(Risedronate & Breast Cancer)

risedronate*

AND

breast neoplasms OR breast cancer[tiab]

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 1

SEARCH #6B(Risedronate & Colon Cancer)

risedronate*

AND

colonic neoplasms OR colon cancer[tiab]

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 0

SEARCH #6C(Risedronate & Lung Cancer)

risedronate*

AND

lung neoplasms OR lung cancer[tiab]

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 1

SEARCH #6D(Risedronate & Osteosarcoma)

risedronate*

AND

osteosarcoma*

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 0

SEARCH #6E(Risedronate & Esophageal Ulcers)

risedronate*

AND

(esophagus OR esophageal) AND ulcer*

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 0

SEARCH #6F(Risedronate & PUBS)

risedronate*

AND

perforation* OR ulcer* OR bleed*

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 0

SEARCH #6G(Risedronate & Osteonecrosis)

risedronate*

AND

osteonecrosis

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 0

SEARCH #7A(Zolendronate & Breast Cancer)

zolendronate* OR zoledronic

AND

breast neoplasms OR breast cancer[tiab]

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 15

SEARCH #7B(Zolendronate & Colon Cancer)

zolendronate* OR zoledronic

AND

colonic neoplasms OR colon cancer[tiab]

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 0

SEARCH #7C(Zolendronate & Lung Cancer)

zolendronate* OR zoledronic

AND

lung neoplasms OR lung cancer[tiab]

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 4

SEARCH #7D(Zolendronate & Osteosarcoma)

zolendronate* OR zoledronic

AND

osteosarcoma*

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 0

SEARCH #7E(Zolendronate & Esophageal Ulcers)

zolendronate* OR zoledronic

AND

(esophagus OR esophageal) AND ulcer*

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 0

SEARCH #7F(Zolendronate & PUBS)

zolendronate* OR zoledronic

AND

perforation* OR ulcer* OR bleed*

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 1

SEARCH #7G(Zolendronate & Osteonecrosis)

zolendronate* OR zoledronic

AND

osteonecrosis

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 18

SEARCH #8A(Raloxifene & Breast Cancer)

raloxifene*

AND

breast neoplasms OR breast cancer[tiab]

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 27

SEARCH #8B(Raloxifene & Colon Cancer)

raloxifene*

AND

colonic neoplasms OR colon cancer[tiab]

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 1

SEARCH #8C(Raloxifene & Lung Cancer)

raloxifene*

AND

lung neoplasms OR lung cancer[tiab]

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 1

SEARCH #8D(Raloxifene & Osteosarcoma)

raloxifene*

AND

osteosarcoma*

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 0

SEARCH #8E(Raloxifene & Esophageal Ulcers)

raloxifene*

AND

(esophagus OR esophageal) AND ulcer*

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 0

SEARCH #8F(Raloxifene & PUBS)

raloxifene*

AND

perforation* OR ulcer* OR bleed*

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 1

SEARCH #8G(Raloxifene & Osteonecrosis)

raloxifene*

AND

osteonecrosis

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 0

SEARCH #9A(Tamoxifen & Breast Cancer)

tamoxifen*

AND

breast neoplasms OR breast cancer[tiab]

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 210

SEARCH #9B(Tamoxifen & Colon Cancer)

tamoxifen*

AND

colonic neoplasms OR colon cancer[tiab]

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 15

SEARCH #9C(Tamoxifen & Lung Cancer)

tamoxifen*

AND

lung neoplasms OR lung cancer[tiab]

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 51

SEARCH #9D(Tamoxifen & Osteosarcoma)

tamoxifen*

AND

osteosarcoma*

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 2

SEARCH #9E(Tamoxifen & Esophageal Ulcers)

tamoxifen*

AND

(esophagus OR esophageal) AND ulcer*

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 0

SEARCH #9F(Tamoxifen & PUBS)

tamoxifen*

AND

perforation* OR ulcer* OR bleed*

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 49

SEARCH #9G(Tamoxifen & Osteonecrosis)

tamoxifen*

AND

osteonecrosis

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 0

SEARCH #10 (PTH & All Diseases)

pth

AND

breast neoplasms OR breast cancer[tiab] OR colonic neoplasms OR colon cancer[tiab]

OR lung neoplasms OR lung cancer[tiab] OR osteosarcoma* OR

((esophagus OR esophageal) AND ulcer*) OR perforation* OR ulcer* OR bleed*

OR osteonecrosis

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 67

SEARCH #11(Testosterone & All Diseases)

testosterone*

AND

breast neoplasms OR breast cancer[tiab] OR colonic neoplasms OR colon cancer[tiab]

OR lung neoplasms OR lung cancer[tiab] OR osteosarcoma* OR

((esophagus OR esophageal) AND ulcer*) OR perforation* OR ulcer* OR bleed*

OR osteonecrosis

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 147

SEARCH #12A(Estrogen & Breast Cancer)

estrogen* OR estrogens[mh] OR oestrogen* OR estradiol

AND

breast neoplasms OR breast cancer[tiab]

AND

cohort*

NOT

testosterone AND (breast neoplasms OR breast cancer[tiab])

NUMBER OF ITEMS RETRIEVED: 602

SEARCH #12B(Estrogen & Colon Cancer)

estrogen* OR estrogens[mh] OR oestrogen* OR estradiol

AND

colonic neoplasms OR colon cancer[tiab]

AND

observational OR cohort* OR case control* OR case report*

NOT

Results of Search #12A

NUMBER OF ITEMS RETRIEVED: 75

SEARCH #12C(Estrogen & Lung Cancer)

estrogen* OR estrogens[mh] OR oestrogen* OR estradiol

AND

lung neoplasms OR lung cancer[tiab]

AND

observational OR cohort* OR case control* OR case report*

NOT

Results of Searches #12A & 12B

NUMBER OF ITEMS RETRIEVED: 122

SEARCH #12D(Estrogen & Osteosarcoma)

estrogen* OR estrogens[mh] OR oestrogen* OR estradiol

AND

osteosarcoma*

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 4

SEARCH #12E(Estrogen & Esophageal Ulcers)

estrogen* OR estrogens[mh] OR oestrogen* OR estradiol

AND

(esophagus OR esophageal) AND ulcer*

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 3

SEARCH #12F(Estrogen & PUBS)

estrogen* OR estrogens[mh] OR oestrogen* OR estradiol

AND

perforation* OR ulcer* OR bleed*

AND

observational OR cohort* OR case control* OR case report*

NOT

Results of Searches #12A–12E

NUMBER OF ITEMS RETRIEVED: 65

SEARCH #12G(Estrogen & Osteonecrosis)

estrogen* OR estrogens[mh] OR oestrogen* OR estradiol

AND

osteonecrosis

AND

observational OR cohort* OR case control* OR case report*

NUMBER OF ITEMS RETRIEVED: 3

SEARCH #13(Calcium & All Diseases)

calcium

AND

breast neoplasms OR breast cancer[tiab] OR colonic neoplasms OR colon cancer[tiab]

OR lung neoplasms OR lung cancer[tiab] OR osteosarcoma* OR

((esophagus OR esophageal) AND ulcer*) OR perforation* OR ulcer* OR bleed*

OR osteonecrosis

AND

cohort*

NUMBER OF ITEMS RETRIEVED :96

SEARCH #14(Vitamin D & All Diseases)

vitamin d

AND

breast neoplasms OR breast cancer[tiab] OR colonic neoplasms OR colon cancer[tiab]

OR lung neoplasms OR lung cancer[tiab] OR osteosarcoma* OR

((esophagus OR esophageal) AND ulcer*) OR perforation* OR ulcer* OR bleed*

OR osteonecrosis

AND

cohort*

NUMBER OF ITEMS RETRIEVED : 42

SEARCH #15A(PubMed Alert #1 - Run from Sept–Dec. 2006)

bisphosphonate* OR alendronate* OR etidronate* OR ibandronate* OR pamidronate* OR risedronate*

AND

randomized controlled trial* OR randomi*[tiab] OR randomized controlled trial[pt]

SEARCH #15B(PubMed Alert #2 - Run from Sept–Dec. 2006)

zolendronate* OR calcitonin* OR miacalcin OR calcimar OR cibacalcin OR calcium OR estrogen* OR estrogens[mh] OR oestrogen* OR estradiol* OR raloxifene* OR teriparatide*

AND

randomized controlled trial* OR randomi*[tiab] OR randomized controlled trial[pt]

SEARCH #15C(PubMed Alert #3 - Run from Sept–Dec. 2006)

testosterone* OR vitamin d* OR glucorticoid*

AND

randomized controlled trial* OR randomi*[tiab] OR randomized controlled trial[pt]

SEARCH #16(Compliance)

DATES SEARCHED: 1995-2006

bisphosphonate* OR alendronate* OR etidronate* OR ibandronate* OR pamidronate* OR risedronate* OR zolendronate* OR calcitonin* OR miacalcin OR calcimar OR cibacalcin OR calcium OR estrogen* OR estrogens[mh] OR oestrogen* OR estradiol* OR raloxifene* OR teriparatide* OR testosterone* OR vitamin d* OR glucorticoid*

AND

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

patient compliance OR patient adherence OR treatment refusal OR non complian* OR non-complian* OR noncomplian* OR non adher* OR non-adher* OR nonadher*

NUMBER OF ITEMS RETRIEVED : 254