# References

1 Christiansen C. (1993). Consensus development conference: diagnosis, prophylaxis, and treatment of osteoporosis. Am J Med.
2 Lindsay R. Osteoporosis. A guide to Diagnosis, Prevention, and Treatment. New York: Raven Press; 1992.
3 Chrischilles EA, Butler CD, Davis CS, et al. (1991). A model of lifetime osteoporosis impact. Arch Intern Med.
4 US Congress OoTA. Hip Fracture Outcomes in People Age 50 and Over-Background Paper. Washington, DC: US Government Printing Office. 1994.
5 Ray NF, Chan JK, Thamer M, et al. (1997). Medical expenditures for the treatment of osteoporotic fractures in the United States in 1995: report from the National Osteoporosis Foundation. J Bone Miner Res.
6 Keen RW. (2003). Burden of osteoporosis and fractures. Curr Osteoporos Rep.
7 Sasser AC, Rousculp MD, Birnbaum HG, et al. (2005). Economic burden of osteoporosis, breast cancer, and cardiovascular disease among postmenopausal women in an employed population. Womens Health Issues.
8 National Osteoporosis Foundation. Physicians Guide to Prevention and Treatment of Osteoporosis. Washington, D.C: National Osteoporosis Foundation; 2006.
9 World Health Organization. Assessment of fracture risk and its implication to screening for postmenopausal osteoporosis: Technical report series 843. Geneva: World Health Organization; 1994.
10 Espallargues M, Sampietro-Colom L, Estrada MD, et al. (2001). Identifying bone-mass-related risk factors for fracture to guide bone densitometry measurements: a systematic review of the literature. Osteoporos Int.
11 Riggs BL, Khosla S, Melton LJ. (2002). Sex steroids and the construction and conservation of the adult skeleton. Endocr Rev.
12 U.S Department of Health and Human Services. Bone Health and Osteoporosis; A Report of the Surgeon General. Rockville, MD: U.S. Department of Health and Human Services, Office of the Surgeon General. 2004.
13 Kanis JA, Johnell O, Oden A, et al. (2005). Smoking and fracture risk: a meta-analysis. Osteoporos Int.
14 Kanis JA, Johansson H, Johnell O, et al. (2005). Alcohol intake as a risk factor for fracture. Osteoporos Int.
15 Tromp AM, Pluijm SM, Smit JH, et al. (2001). Fall-risk screening test: a prospective study on predictors for falls in community-dwelling elderly. J Clin Epidemiol.
16 Chu LW, Chi I, Chiu AY. (2005). Incidence and predictors of falls in the chinese elderly. Ann Acad Med Singapore.
17 Tinetti ME, Speechley M, Ginter SF. (1988). Risk factors for falls among elderly persons living in the community. N Engl J Med.
18 Campbell AJ, Borrie MJ, Spears GF. (1989). Risk factors for falls in a community-based prospective study of people 70 years and older. J Gerontol.
19 Institute of Medicine. Dietary Reference Intakes for Calcium, Phosphorus, Magnesium, Vitamin D, and Fluroide. Standing Committee on the Scientific Evaluation of Dietary Reference Intakes, Food and Nutrition Board. Washington, D.C: National Academy Press; 1997.
20 Rubenstein LZ, Powers CM, MacLean CH. (2001). Quality indicators for the management and prevention of falls and mobility problems in vulnerable elders. Ann Intern Med.
21 Colman EG. (2003). The Food and Drug Administration's Osteoporosis Guidance Document: past, present, and future. J Bone Miner Res.
22 Muchmore DB. (2000). Raloxifene: A selective estrogen receptor modulator (SERM) with multiple target system effects. Oncologist.
23 Wetzels GE, Nelemans P, Schouten JS, et al. (2004). Facts and fiction of poor compliance as a cause of inadequate blood pressure control: a systematic review. J Hypertens.
24 Caro JJ, Salas M, Speckman JL, et al. (1999). Persistence with treatment for hypertension in actual practice. CMAJ.
25 Avorn J, Monette J, Lacour A, et al. (1998). Persistence of use of lipid-lowering medications: a cross-national study. JAMA.
26 Benner JS, Glynn RJ, Mogun H, et al. (2002). Long-term persistence in use of statin therapy in elderly patients. JAMA.
27 Moher D, Cook DJ, Eastwood S, et al. (1999). Improving the quality of reports of meta-analyses of randomised controlled trials: the QUOROM statement. Quality of Reporting of Meta-analyses. Lancet.
28 Jadad AR, Moore RA, Carroll D, et al. (1996). Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials.
29 Moher D, Pham B, Jones A, et al. (1998). Does quality of reports of randomised trials affect estimates of intervention efficacy reported in meta-analyses?. Lancet.
30 Fullerton DS, Atherly DS. (2004). Formularies, therapeutics, and outcomes: new opportunities. Med Care.
31 Atkins D, Best D, Briss PA, et al. (2004). Grading quality of evidence and strength of recommendations. BMJ.
32 Yusuf S, Peto R, Lewis J, et al. (1985). Beta blockade during and after myocardial infarction: an overview of the randomized trials. Prog Cardiovasc Dis.
33 Bradburn MJ, Deeks JJ, Berlin JA, et al. Much ado about nothing: a comparison of the performance of meta-analytical methods with rare events. Stat Med 2006.
34 Hedges LV, Olkin I. Statistical Methods for Meta-Analysis. San Deigo, CA: Academic Press Inc; 1985.
35 Higgins JP, Thompson SG, Deeks JJ, et al. (2003). Measuring inconsistency in meta-analyses. BMJ.
36 Version 9.0. College Station, Texas: Stata Corp.; 2005.
37 Gass M, Dawson-Hughes B. (2006). Preventing osteoporosis-related fractures: an overview. Am J Med.
38 StatXact 7 for Windows [computer program]. Version Version 7.0.1. Cambridge, MA: Cytel Software Corporation; 2005.
39 Cranney A, Wells G, Willan A, et al. (2002). Meta-analyses of therapies for postmenopausal osteoporosis. II. Meta-analysis of alendronate for the treatment of postmenopausal women. Endocr Rev.
40 Karpf DB, Shapiro DR, Seeman E, et al. (1997). Prevention of nonvertebral fractures by alendronate. A meta-analysis. Alendronate Osteoporosis Treatment Study Groups. JAMA.
41 Cranney A, Welch V, Adachi JD, et al. Etidronate for treating and preventing postmenopausal osteoporosis. Cochrane Database of Systematic Reviews 2005;(3)
42 Cranney A, Adachi JD, Homik JJEH, et al. Calcitonin for preventing and treating corticosteroid-induced osteoporosis. Cochrane Database of Systematic Reviews 2005;(3)
43 Papapoulos SE, Quandt SA, Liberman UA, et al. (2005). Meta-analysis of the efficacy of alendronate for the prevention of hip fractures in postmenopausal women. Osteoporos Int.
44 Cranney A, Tugwell P, Adachi J, et al. (2002). Meta-analyses of therapies for postmenopausal osteoporosis. III. Meta-analysis of risedronate for the treatment of postmenopausal osteoporosis. Endocr Rev.
45 Cranney A, Tugwell P, Zytaruk N, et al. (2002). Meta-analyses of therapies for postmenopausal osteoporosis. VI. Meta-analysis of calcitonin for the treatment of postmenopausal osteoporosis. Endocr Rev.
46 Kanis JA, McCloskey EV. (1999). Effect of calcitonin on vertebral and other fractures. QJM.
47 Stevenson M, Lloyd Jones M, De Nigris E, et al. (2005). A systematic review and economic evaluation of alendronate, etidronate, risedronate, raloxifene and teriparatide for the prevention and treatment of postmenopausal osteoporosis. Health Technol Assess.
48 Schachter HM, Clifford TJ, Cranney A, Barrowman NJ, Moher D. Raloxifene for primary and secondary prevention of osteoporotic fractures in postmenopausal women: a systematic review of efficacy and safety evidence. Ottawa, Canada: Canadian Coordinating Office for Health Technology Assessment. 2005.
49 Shea B, Wells G, Cranney A, et al. (2002). Meta-analyses of therapies for postmenopausal osteoporosis. VII. Meta-analysis of calcium supplementation for the prevention of postmenopausal osteoporosis. Endocr Rev.
50 Papadimitropoulos E, Wells G, Shea B, et al. (2002). Meta-analyses of therapies for postmenopausal osteoporosis. VIII: Meta-analysis of the efficacy of vitamin D treatment in preventing osteoporosis in postmenopausal women. Endocr Rev.
51 Avenell A, Gillespie WJ, Gillespie LD, et al. Vitamin D and vitamin D analogues for preventing fractures associated with involutional and post-menopausal osteoporosis. Cochrane Database Syst Rev 2005;(3):CD000227.
52 Bischoff-Ferrari HA, Willett WC, Wong JB, et al. (2005). Fracture prevention with vitamin D supplementation: a meta-analysis of randomized controlled trials. JAMA.
53 Torgerson DJ, Bell-Syer SE. (2001). Hormone replacement therapy and prevention of vertebral fractures: a meta-analysis of randomised trials. BMC Musculoskelet Disord.
54 Wells G, Tugwell P, Shea B, et al. (2002). Meta-analyses of therapies for postmenopausal osteoporosis. V. Meta-analysis of the efficacy of hormone replacement therapy in treating and preventing osteoporosis in postmenopausal women. Endocr Rev.
55 Seeman E, Crans GG, Diez-Perez A, et al. (2006). Anti-vertebral fracture efficacy of raloxifene: a meta-analysis. Osteoporos Int.
56 Nguyen ND, Eisman JA, Nguyen TV. (2006). Anti-hip fracture efficacy of biophosphonates: a Bayesian analysis of clinical trials. J Bone Miner Res.
57 Sawka AM, Papaioannou A, Adachi JD, et al. (2005). Does alendronate reduce the risk of fracture in men? A meta-analysis incorporating prior knowledge of anti-fracture efficacy in women. BMC Musculoskelet Disord.
58 Richy F, Schacht E, Bruyere O, et al. (2005). Vitamin D analogs versus native vitamin D in preventing bone loss and osteoporosis-related fractures: a comparative meta-analysis. Calcif Tissue Int.
59 Palmer S, McGregor DO, Strippoli GF. Interventions for preventing bone disease in kidney transplant recipients. Cochrane Database Syst Rev 2005;(2):CD005015.
60 Miller PD, Roux C, Boonen S, et al. (2005). Safety and efficacy of risedronate in patients with age-related reduced renal function as estimated by the Cockcroft and Gault method: a pooled analysis of nine clinical trials. J Bone Miner Res.
61 Richy F, Ethgen O, Bruyere O, et al. (2004). Efficacy of alphacalcidol and calcitriol in primary and corticosteroid-induced osteoporosis: a meta-analysis of their effects on bone mineral density and fracture rate. Osteoporos Int.
62 Boonen S, Laan RF, Barton IP, et al. (2005). Effect of osteoporosis treatments on risk of non-vertebral fractures: review and meta-analysis of intention-to-treat studies. Osteoporos Int.
63 Jackson RD, LaCroix AZ, Gass M, et al. (2006). Calcium plus vitamin D supplementation and the risk of fractures. N Engl J Med.
64 Porthouse J, Cockayne S, King C, et al. (2005). Randomised controlled trial of calcium and supplementation with cholecalciferol (vitamin D3) for prevention of fractures in primary care. BMJ.
65 Grant AM, Avenell A, Campbell MK, et al. (2005). Oral vitamin D3 and calcium for secondary prevention of low-trauma fractures in elderly people (Randomised Evaluation of Calcium Or vitamin D, RECORD): a randomised placebo-controlled trial. Lancet.
66 Bone HG, Greenspan SL, McKeever C, et al. (2000). Alendronate and estrogen effects in postmenopausal women with low bone mineral density. Alendronate/Estrogen Study Group. J Clin Endocrinol Metab.
67 Greenspan SL, Resnick NM, Parker RA. (2003). Combination therapy with hormone replacement and alendronate for prevention of bone loss in elderly women: a randomized controlled trial. JAMA.
68 Hosking D, Adami S, Felsenberg D, et al. (2003). Comparison of change in bone resorption and bone mineral density with once-weekly alendronate and daily risedronate: a randomised, placebo-controlled study. Current medical research and opinion.
69 McClung MR, Lewiecki EM, Cohen SB, et al. (2006). Denosumab in postmenopausal women with low bone mineral density. N Engl J Med.
70 Quandt SA, Thompson DE, Schneider DL, et al. (2005). Effect of alendronate on vertebral fracture risk in women with bone mineral density T scores of-1.6 to -2.5 at the femoral neck: the Fracture Intervention Trial. Mayo Clin Proc.
71 Zein CO, Jorgensen RA, Clarke B, et al. (2005). Alendronate improves bone mineral density in primary biliary cirrhosis: a randomized placebo-controlled trial. Hepatology.
72 Sato Y, Iwamoto J, Kanoko T, et al. Alendronate and vitamin D2 for prevention of hip fracture in Parkinson's disease: A randomized controlled trial. Mov Disord 2006.
73 Adami S, Passeri M, Ortolani S, et al. (1995). Effects of oral alendronate and intranasal salmon calcitonin on bone mass and biochemical markers of bone turnover in postmenopausal women with osteoporosis. Bone.
74 Black DM, Cummings SR, Karpf DB, et al. (1996). Randomised trial of effect of alendronate on risk of fracture in women with existing vertebral fractures. Fracture Intervention Trial Research Group. Lancet.
75 Bone HG, Downs RW, Tucci JR, et al. (1997). Dose-response relationships for alendronate treatment in osteoporotic elderly women. Alendronate Elderly Osteoporosis Study Centers. J Clin Endocrinol Metab.
76 Bonnick S, Rosen C, Mako B, et al. (1998). Alendronate vs calcium for treatment of osteoporosis in postmenopausal women. Bone.
77 Chesnut CH, McClung MR, Ensrud KE, et al. (1995). Alendronate treatment of the postmenopausal osteoporotic woman: effect of multiple dosages on bone mass and bone remodeling. The American journal of medicine.
78 Cummings SR, Black DM, Thompson DE, et al. (1998). Effect of alendronate on risk of fracture in women with low bone density but without vertebral fractures: results from the Fracture Intervention Trial. JAMA.
79 Dursun N, Dursun E, Yalcin S. (2001). Comparison of alendronate, calcitonin and calcium treatments in postmenopausal osteoporosis. Int J Clin Pract.
80 Greenspan SL, Parker RA, Ferguson L, et al. (1998). Early changes in biochemical markers of bone turnover predict the long-term response to alendronate therapy in representative elderly women: a randomized clinical trial. J Bone Miner Res.
81 Greenspan SL, Schneider DL, McClung MR, et al. (2002). Alendronate improves bone mineral density in elderly women with osteoporosis residing in long-term care facilities. A randomized, double-blind, placebo-controlled trial.[summary for patients in Ann Intern Med. 2002 May 21;136(10):I54; PMID: 12020160]. Annals of Internal Medicine.
82 Hosking D, Chilvers CE, Christiansen C, et al. (1998). Prevention of bone loss with alendronate in postmenopausal women under 60 years of age. Early Postmenopausal Intervention Cohort Study Group. N Engl J Med.
83 Liberman UA, Weiss SR, Broll J, et al. (1995). Effect of oral alendronate on bone mineral density and the incidence of fractures in postmenopausal osteoporosis. The Alendronate Phase III Osteoporosis Treatment Study Group. N Engl J Med.
84 McClung M, Clemmesen B, Daifotis A, et al. (1998). Alendronate prevents postmenopausal bone loss in women without osteoporosis. A double-blind, randomized, controlled trial. Alendronate Osteoporosis Prevention Study Group. Annals of internal medicine.
85 Orwoll E, Ettinger M, Weiss S, et al. (2000). Alendronate for the treatment of osteoporosis in men. N Engl J Med.
86 Pols HA, Felsenberg D, Hanley DA, et al. (1999). Multinational, placebo-controlled, randomized trial of the effects of alendronate on bone density and fracture risk in postmenopausal women with low bone mass: results of the FOSIT study. Foxamax International Trial Study Group. Osteoporos Int.
87 Ringe JD, Dorst A, Faber H, et al. (2004). Alendronate treatment of established primary osteoporosis in men: 3-year results of a prospective, comparative, two-arm study. Rheumatol Int.
88 Weinstein RS, Bone H, Tucci J, et al. (1994). Alendronate treatment of osteoporosis in elderly women. J Bone Miner Res.
89 Sato Y, Kanoko T, Yasuda H, et al. (2004). Beneficial effect of etidronate therapy in immobilized hip fracture patients. Am J Phys Med Rehabil.
90 Sato Y, Honda Y, Iwamoto J. Etidronate for fracture prevention in amyotrophic lateral sclerosis: A randomized controlled trial. Bone 2006.
91 Wimalawansa SJ. (1998). A four-year randomized controlled trial of hormone replacement and bisphosphonate, alone or in combination, in women with postmenopausal osteoporosis. Am J Med.
92 Campbell IA, Douglas JG, Francis RM, et al. (2004). Five year study of etidronate and/or calcium as prevention and treatment for osteoporosis and fractures in patients with asthma receiving long term oral and/or inhaled glucocorticoids. Thorax.
93 Ishida Y, Kawai S. (2004). Comparative efficacy of hormone replacement therapy, etidronate, calcitonin, alfacalcidol, and vitamin K in postmenopausal women with osteoporosis: The Yamaguchi Osteoporosis Prevention Study. The American Journal of Medicine.
94 Sato S, Ohosone Y, Suwa A, et al. (2003). Effect of intermittent cyclical etidronate therapy on corticosteroid induced osteoporosis in Japanese patients with connective tissue disease: 3 year followup. J Rheumatol.
95 Herd RJ, Balena R, Blake GM, et al. (1997). The prevention of early postmenopausal bone loss by cyclical etidronate therapy: a 2-year, double-blind, placebo-controlled study. Am J Med.
96 Iwamoto J TTIS. Effect of menatetrenone on bone mineral density and incidence of vertebral fractures in postmenopausal women with osteoporosis: a comparison with the effect of etidronate. Journal of orthopaedic science : official journal of the Japanese Orthopaedic Association. 2001;6(6):487–92.
97 Lyritis GP, Tsakalakos N, Paspati I, et al. (1997). The effect of a modified etidronate cyclical regimen on postmenopausal osteoporosis: a four-year study. Clin Rheumatol.
98 Meunier PJ, Confavreux E, Tupinon I, et al. (1997). Prevention of early postmenopausal bone loss with cyclical etidronate therapy (a double-blind, placebo-controlled study and 1-year follow-up). J Clin Endocrinol Metab.
99 Montessori ML, Scheele WH, Netelenbos JC, et al. (1997). The use of etidronate and calcium versus calcium alone in the treatment of postmenopausal osteopenia: results of three years of treatment. Osteoporosis international : a journal established as result of cooperation between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
100 Pacifici R, McMurtry C, Vered I, et al. (1988). Coherence therapy does not prevent axial bone loss in osteoporotic women: a preliminary comparative study. J Clin Endocrinol Metab.
101 Pouilles JM, Tremollieres F, Roux C, et al. (1997). Effects of cyclical etidronate therapy on bone loss in early postmenopausal women who are not undergoing hormonal replacement therapy. Osteoporosis international : a journal established as result of cooperation between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
102 Storm T, Thamsborg G, Steiniche T, et al. (1990). Effect of intermittent cyclical etidronate therapy on bone mass and fracture rate in women with postmenopausal osteoporosis. N Engl J Med.
103 Watts NB, Harris ST, Genant HK, et al. (1990). Intermittent cyclical etidronate treatment of postmenopausal osteoporosis. N Engl J Med.
104 Ravn P, Clemmesen B, Riis BJ, et al. (1996). The effect on bone mass and bone markers of different doses of ibandronate: a new bisphosphonate for prevention and treatment of postmenopausal osteoporosis: a 1-year, randomized, double-blind, placebo-controlled dose-finding study. Bone.
105 Chesnut CH, Skag A, Christiansen C, et al. (2004). Effects of oral ibandronate administered daily or intermittently on fracture risk in postmenopausal osteoporosis. Journal of bone and mineral research : the official journal of the American Society for Bone and Mineral Research.
106 Recker R, Stakkestad JA, Chesnut CH, et al. (2004). Insufficiently dosed intravenous ibandronate injections are associated with suboptimal antifracture efficacy in postmenopausal osteoporosis. Bone.
107 Grotz W, Nagel C, Poeschel D, et al. (2001). Effect of ibandronate on bone loss and renal function after kidney transplantation. Journal of the American Society of Nephrology : JASN.
108 Jiang Y, Zhao JJ, Mitlak BH, et al. (2003). Recombinant human parathyroid hormone (1–34) teriparatide improves both cortical and cancellous bone structure. Journal of bone and mineral research : the official journal of the American Society for Bone and Mineral Research.
109 Kim SH, Lim SK, Hahn JS. (2004). Effect of pamidronate on new vertebral fractures and bone mineral density in patients with malignant lymphoma receiving chemotherapy. The American journal of medicine.
110 Ninkovic M, Love S, Tom BD, et al. (2002). Lack of effect of intravenous pamidronate on fracture incidence and bone mineral density after orthotopic liver transplantation. J Hepatol.
111 Aris RM, Lester GE, Renner JB, et al. (2000). Efficacy of pamidronate for osteoporosis in patients with cystic fibrosis following lung transplantation. American journal of respiratory and critical care medicine.
112 Reid IR, Wattie DJ, Evans MC, et al. (1994). Continuous therapy with pamidronate, a potent bisphosphonate, in postmenopausal osteoporosis. J Clin Endocrinol Metab.
113 Kananen K, Volin L, Laitinen K, et al. (2005). Prevention of bone loss after allogeneic stem cell transplantation by calcium, vitamin D, and sex hormone replacement with or without pamidronate. J Clin Endocrinol Metab.
114 Coco M, Glicklich D, Faugere MC, et al. (2003). Prevention of bone loss in renal transplant recipients: a prospective, randomized trial of intravenous pamidronate. Journal of the American Society of Nephrology : JASN.
115 Watts NB, Josse RG, Hamdy RC, et al. (2003). Risedronate prevents new vertebral fractures in postmenopausal women at high risk. J Clin Endocrinol Metab.
116 Wallach S, Cohen S, Reid DM, et al. (2000). Effects of risedronate treatment on bone density and vertebral fracture in patients on corticosteroid therapy. Calcif Tissue Int.
117 Sorensen OH, Crawford GM, Mulder H, et al. (2003). Long-term efficacy of risedronate: a 5-year placebo-controlled clinical experience. Bone.
118 Sato Y, Kanoko T, Satoh K, et al. (2005). The prevention of hip fracture with risedronate and ergocalciferol plus calcium supplementation in elderly women with Alzheimer disease: a randomized controlled trial. Arch Intern Med.
119 Sato Y, Iwamoto J, Kanoko T, et al. (2005). Risedronate therapy for prevention of hip fracture after stroke in elderly women. Neurology.
120 Palomba S, Orio F, Manguso F, et al. (2005). Efficacy of risedronate administration in osteoporotic postmenopausal women affected by inflammatory bowel disease. Osteoporos Int.
121 Hooper MJ, Ebeling PR, Roberts AP, et al. (2005). Risedronate prevents bone loss in early postmenopausal women: a prospective randomized, placebo-controlled trial. Climacteric.
122 Greenspan SL, Bhattacharya RK, Sereika SM, et al. Prevention of Bone Loss in Survivors of Breast Cancer: A Randomized, Double-Blind, Placebo-Controlled Clinical Trial. J Clin Endocrinol Metab 2006.
123 Milgrom C, Finestone A, Novack V, et al. (2004). The effect of prophylactic treatment with risedronate on stress fracture incidence among infantry recruits. Bone.
124 Sato Y, Iwamoto J, Kanoko T, et al. (2005). Risedronate sodium therapy for prevention of hip fracture in men 65 years or older after stroke. Arch Intern Med.
125 Kanaji A, Higashi M, Namisato M, et al. (2006). Effects of risedronate on lumbar bone mineral density, bone resorption, and incidence of vertebral fracture in elderly male patients with leprosy. Lepr Rev.
126 Kishimoto H, Fukunaga M, Kushida K, et al. (2006). Efficacy and tolerability of once-weekly administration of 17.5 mg risedronate in Japanese patients with involutional osteoporosis: a comparison with 2.5-mg once-daily dosage regimen. J Bone Miner Metab.
127 Harris ST, Watts NB, Li Z, et al. (2004). Two-year efficacy and tolerability of risedronate once a week for the treatment of women with postmenopausal osteoporosis. Curr Med Res Opin.
128 Brown JP, Kendler DL, McClung MR, et al. (2002). The efficacy and tolerability of risedronate once a week for the treatment of postmenopausal osteoporosis. Calcif Tissue Int.
129 Clemmesen B, Ravn P, Zegels B, et al. (1997). A 2-year phase II study with 1-year of follow-up of risedronate (NE-58095) in postmenopausal osteoporosis. Osteoporos Int.
130 Fogelman I, Ribot C, Smith R, et al. (2000). Risedronate reverses bone loss in postmenopausal women with low bone mass: results from a multinational, double-blind, placebo-controlled trial. BMD-MN Study Group. J Clin Endocrinol Metab.
131 Harris ST, Watts NB, Genant HK, et al. (1999). Effects of risedronate treatment on vertebral and nonvertebral fractures in women with postmenopausal osteoporosis: a randomized controlled trial. Vertebral Efficacy With Risedronate Therapy (VERT) Study Group. JAMA.
132 McClung M, Bensen W, Bolognese M, et al. (1998). Risedronate increases bone mineral density at the hip, spine and radius in postmenopausal women with low bone mass. Osteoporosis International.
133 McClung MR, Geusens P, Miller PD, et al. (2001). Effect of risedronate on the risk of hip fracture in elderly women. Hip Intervention Program Study Group. N Engl J Med.
134 Mortensen L, Charles P, Bekker PJ, et al. (1998). Risedronate increases bone mass in an early postmenopausal population: two years of treatment plus one year of follow-up. J Clin Endocrinol Metab.
135 Reginster J, Minne HW, Sorensen OH, et al. (2000). Randomized trial of the effects of risedronate on vertebral fractures in women with established postmenopausal osteoporosis. Vertebral Efficacy with Risedronate Therapy (VERT) Study Group. Osteoporos Int.
136 Reid DM, Hughes RA, Laan RF, et al. (2000). Efficacy and safety of daily risedronate in the treatment of corticosteroid-induced osteoporosis in men and women: a randomized trial. European Corticosteroid-Induced Osteoporosis Treatment Study. J Bone Miner Res.
137 Cohen S, Levy RM, Keller M, et al. (1999). Risedronate therapy prevents corticosteroid-induced bone loss: a twelve-month, multicenter, randomized, double-blind, placebo-controlled, parallel-group study. Arthritis Rheum.
138 Reid IR, Brown JP, Burckhardt P, et al. (2002). Intravenous zoledronic acid in postmenopausal women with low bone mineral density. N Engl J Med.
139 Black DM, Delmas PD, Eastell R, et al. (2007). Once-yearly zoledronic acid for treatment of postmenopausal osteoporosis. N Engl J Med.
140 Trovas GP, Lyritis GP, Galanos A, et al. (2002). A randomized trial of nasal spray salmon calcitonin in men with idiopathic osteoporosis: effects on bone mineral density and bone markers. J Bone Miner Res.
141 Ushiroyama T, Ikeda A, Sakai M, et al. (2001). Effects of the combined use of calcitonin and 1 alpha-hydroxycholecalciferol on vertebral bone loss and bone turnover in women with postmenopausal osteopenia and osteoporosis: a prospective study of long-term and continuous administration with low dose calcitonin. Maturitas.
142 Toth E, Csupor E, Meszaros S, et al. (2005). The effect of intranasal salmon calcitonin therapy on bone mineral density in idiopathic male osteoporosis without vertebral fractures—an open label study. Bone.
143 Hay JE, Malinchoc M, Dickson ER. (2001). A controlled trial of calcitonin therapy for the prevention of post-liver transplantation atraumatic fractures in patients with primary biliary cirrhosis and primary sclerosing cholangitis. J Hepatol.
144 Arnala I, Saastamoinen J, Alhava EM. (1996). Salmon calcitonin in the prevention of bone loss at perimenopause. Bone.
145 Agrawal R, Wallach S, Cohn S, et al. Calcitonin treatment in osteoporosis. In: Calcitonin 1980. Proceedings of an international symposium held in Milan, October 1980. Excerpta Medica 1980;237–46.
146 Chesnut CH, Silverman S, Andriano K, et al. (2000). A randomized trial of nasal spray salmon calcitonin in postmenopausal women with established osteoporosis: the prevent recurrence of osteoporotic fractures study. PROOF Study Group. Am J Med.
147 Gennari C, Chierichetti SM, Bigazzi S, et al. Comparative effects on bone mineral content of calcium and calcium plus salmon calcitonin given in two different regimens in postmenopausal osteoporosis. Curr 1985;THER. RES., CLIN. EXP. 38(3):455–464.
148 Grotz WH, Rump LC, Niessen A, et al. (1998). Treatment of osteopenia and osteoporosis after kidney transplantation. Transplantation.
149 Gruber HE, Ivey JL, Baylink DJ, et al. (1984). Long-term calcitonin therapy in postmenopausal osteoporosis. Metabolism.
150 Healey JH, Paget SA, Williams-Russo P, et al. (1996). A randomized controlled trial of salmon calcitonin to prevent bone loss in corticosteroid-treated temporal arteritis and polymyalgia rheumatica. Calcif Tissue Int.
151 Hizmetli S, Elden H, Kaptanoglu E, et al. (1998). The effect of different doses of calcitonin on bone mineral density and fracture risk in postmenopausal osteoporosis. Int J Clin Pract.
152 Luengo M, Pons F, Martinez de Osaba MJ, et al. (1994). Prevention of further bone mass loss by nasal calcitonin in patients on long term glucocorticoid therapy for asthma: a two year follow up study. Thorax.
153 Nordal KP, Halse J, Dahl E. The effect of nasal calcitonin on bone mineral density in renal transplant recipients. 1996;
154 Overgaard K, Hansen MA, Jensen SB, et al. (1992). Effect of salcatonin given intranasally on bone mass and fracture rates in established osteoporosis: a dose-response study. BMJ.
155 Peyron R, Serrurier D, Edouard C, Ghozlan R, Mayoux-Benhamon A, Meunier PJ. Treatment of high remodelling vertebral osteoporosis with human calcitonin: a two year double-blind placebo-controlled trial in 93 patients. In: Christiansen C, Overgaard Ke. Osteoporosis. Copenhagen: Osteopress; 1990. p. 1430–3.
156 Rico H, Hernandez ER, Revilla M, et al. (1992). Salmon calcitonin reduces vertebral fracture rate in postmenopausal crush fracture syndrome. Bone Miner.
157 Rico H, Revilla M, Hernandez ER, et al. (1995). Total and regional bone mineral content and fracture rate in postmenopausal osteoporosis treated with salmon calcitonin: a prospective study. Calcif Tissue Int.
158 Ringe JD. (1990). [Treatment of primary osteoporosis with calcium and salmon calcitonin]. Deutsche medizinische Wochenschrift.
159 Ringe JD, Welzel D. (1987). Salmon calcitonin in the therapy of corticoid-induced osteoporosis. European journal of clinical pharmacology.
160 Sambrook P, Birmingham J, Kelly P. (1993). Prevention of corticosteroid-induced osteoporosis. NEJM.
161 Stock JL, Avioli LV, Baylink DJ. (1997). Calcitonin-salmon nasal spray reduces the incidence of new vertebral fractures in post-menopausal women: three-year interim results of the PROOF study. J Bone Miner Res.
162 Torgerson DJ, Bell-Syer SE. (2001). Hormone replacement therapy and prevention of nonvertebral fractures: a meta-analysis of randomized trials. JAMA.
163 Cauley JA, Robbins J, Chen Z, et al. (2003). Effects of estrogen plus progestin on risk of fracture and bone mineral density: the Women's Health Initiative randomized trial. JAMA.
164 Rossouw JE, Anderson GL, Prentice RL, et al. (2002). Risks and benefits of estrogen plus progestin in healthy postmenopausal women: principal results From the Women's Health Initiative randomized controlled trial. JAMA.
165 Anderson GL, Limacher M, Assaf AR, et al. (2004). Effects of conjugated equine estrogen in postmenopausal women with hysterectomy: the Women's Health Initiative randomized controlled trial. JAMA.
166 Reid IR, Eastell R, Fogelman I, et al. (2004). A comparison of the effects of raloxifene and conjugated equine estrogen on bone and lipids in healthy postmenopausal women. Arch Intern Med.
167 Aitken JM, Hart DM, Lindsay R. (1973). Oestrogen replacement therapy for prevention of osteoporosis after oophorectomy. Br Med J.
168 Alexandersen P, Riis BJ, Christiansen C. (1999). Monofluorophosphate combined with hormone replacement therapy induces a synergistic effect on bone mass by dissociating bone formation and resorption in postmenopausal women: a randomized study. J Clin Endocrinol Metab.
169 Bjarnason NH, Byrjalsen I, Hassager C, et al. (2000). Low doses of estradiol in combination with gestodene to prevent early postmenopausal bone loss. Am J Obstet Gynecol.
170 Cauley JA, Black DM, Barrett-Connor E, et al. (2001). Effects of hormone replacement therapy on clinical fractures and height loss: The Heart and Estrogen/Progestin Replacement Study (HERS). Am J Med.
171 Cheng S, Sipila S, Puolakka H, et al. (2000). Effects of hormone replacement therapy and high impact physical exercise on bone/muscle ratio in postmenopausal women. Osteoporos Int.
172 Delmas PD, Confavreux E, Garnero P, et al. (2000). A combination of low doses of 17 beta-estradiol and norethisterone acetate prevents bone loss and normalizes bone turnover in postmenopausal women. Osteoporos Int.
173 Eiken P, Nielsen SP, Kolthoff N. (1997). Effects on bone mass after eight years of hormonal replacement therapy. Br J Obstet Gynaecol.
174 Gallagher JC, Fowler SE, Detter JR, et al. (2001). Combination treatment with estrogen and calcitriol in the prevention of age-related bone loss. J Clin Endocrinol Metab.
175 Genant HK, Lucas J, Weiss S, et al. (1997). Low-dose esterified estrogen therapy: effects on bone, plasma estradiol concentrations, endometrium, and lipid levels. Estratab/Osteoporosis Study Group. Arch Intern Med.
176 Greenspan S, Bankhurst A, Bell N. Effects of alendronate and estrogen alone and in combination on bone mass and turnover in postmenopausal osteoporosis. J Bone Miner Res 1998;S174 (Abstract 1107).
177 Herrington DM, Reboussin DM, Brosnihan KB, et al. (2000). Effects of estrogen replacement on the progression of coronary-artery atherosclerosis. N Engl J Med.
178 Hully S, Grady D, Bush T, et al. (1998). Randomized trial of estrogen plus progestin for secondary prevention of coronary heart disease in postemenopausal women. JAMA.
179 Ishida Y, Soh H, Tsuchida M, et al. (2001). Comarison of the effectiveness of hormone replacement therapy, bisphosphonate, calcitonin, vitamin D and vitamin K in postmenopausal. Bone.
180 Komulainen M, Tuppurainen MT, Kroger H, et al. (1997). Vitamin D and HRT: no benefit additional to that of HRT alone in prevention of bone loss in early postmenopausal women. A 2.5-year randomized placebo-controlled study. Osteoporosis Int.
181 Komulainen MH, Kroger H, Tuppurainen MT, et al. (1998). HRT and Vit D in prevention of non-vertebral fractures in postmenopausal women; a 5 year randomized trial. Maturitas.
182 Lees B, Stevenson JC. (2001). The prevention of osteoporosis using sequential low-dose hormone replacement therapy with estradiol-17 beta and dydrogesterone. Osteoporos Int.
183 Lindsay R, Tohme JF. (1990). Estrogen treatment of patients with established postmenopausal osteoporosis. Obstet Gynecol.
184 Lufkin EG, Wahner HW, O'Fallon WM, et al. (1992). Treatment of postmenopausal osteoporosis with transdermal estrogen. Ann Intern Med.
185 Mosekilde L, Beck-Nielsen H, Sorensen OH, et al. (2000). Hormonal replacement therapy reduces forearm fracture incidence in recent postmenopausal women - results of the Danish Osteoporosis Prevention Study. Maturitas.
186 Mulnard RA, Cotman CW, Kawas C, et al. (2000). Estrogen replacement therapy for treatment of mild to moderate Alzheimer disease: a randomized controlled trial. Alzheimer's Disease Cooperative Study. JAMA.
187 Nachtigall LE, Nachtigall RH, Nachtigall RD, et al. (1979). Estrogen replacement therapy I: a 10-year prospective study in the relationship to osteoporosis. Obstet Gynecol.
188 Orr-Walker BJ, Evans MC, Clearwater JM, et al. (2000). Effects of hormone replacement therapy on bone mineral density in postmenopausal women with primary hyperparathyroidism: four-year follow-up and comparison with healthy postmenopausal women. Arch Intern Med.
189 Effects of hormone therapy on bone mineral density: results from the postmenopausal estrogen/progestin interventions (PEPI) trial. The Writing Group for the PEPI. JAMA 1996;276(17):1389–96.
190 Ravn P, Bidstrup M, Wasnich RD, et al. (1999). Alendronate and estrogen-progestin in the long-term prevention of bone loss: four-year results from the early postmenopausal intervention cohort study. A randomized, controlled trial. Annals of internal medicine.
191 Recker RR, Davies KM, Dowd RM, et al. (1999). The effect of low-dose continuous estrogen and progesterone therapy with calcium and vitamin D on bone in elderly women. A randomized, controlled trial. Ann Intern Med.
192 Stevenson JC, Lees B. (2000). Bone conserving effects of oestrogen are dose-dependent for age and time since menopause. Osteoporos Int.
193 Weiss SR, Ellman H, Dolker M. (1999). A randomized controlled trial of four doses of transdermal estradiol for preventing postmenopausal bone loss. Transdermal Estradiol Investigator Group. Obstet Gynecol.
194 Gallagher JC, Genant HK, Crans GG, et al. (2005). Teriparatide reduces the fracture risk associated with increasing number and severity of osteoporotic fractures. The Journal of clinical endocrinology and metabolism.
195 Orwoll ES, Scheele WH, Paul S. (2003). The effects of teriparatide[human parathyroid hormone(1–34)] therapy on bone density in men with osteoporosis. J Bone Miner Res.
196 Kaufman JM, Orwoll E, Goemaere S, et al. (2005). Teriparatide effects on vertebral fractures and bone mineral density in men with osteoporosis: treatment and discontinuation of therapy. Osteoporos Int.
197 Cosman F, Nieves J, Woelfert L, et al. (2001). Parathyroid hormone added to established hormone therapy: effects on vertebral fracture and maintenance of bone mass after parathyroid hormone withdrawal. J Bone Miner Res.
198 Neer RM, Arnaud CD, Zanchetta JR, et al. (2001). Effect of parathyroid hormone (1–34) on fractures and bone mineral density in postmenopausal women with osteoporosis. N Engl J Med.
199 Barrett-Connor E, Mosca L, Collins P, et al. (2006). Effects of raloxifene on cardiovascular events and breast cancer in postmenopausal women. N Engl J Med.
200 Ettinger B, Black DM, Mitlak BH, et al. (1999). Reduction of vertebral fracture risk in postmenopausal women with osteoporosis treated with raloxifene: results from a 3-year randomized clinical trial. Multiple Outcomes of Raloxifene Evaluation (MORE) Investigators. JAMA.
201 Jolly EE, Bjarnason NH, Neven P, et al. (2003). Prevention of osteoporosis and uterine effects in postmenopausal women taking raloxifene for 5 years. Menopause.
202 Lufkin EG, Whitaker MD, Nickelsen T, et al. (1998). Treatment of established postmenopausal osteoporosis with raloxifene: a randomized trial. J Bone Miner Res.
203 Morii H, Ohashi Y, Taketani Y, et al. (2003). Effect of raloxifene on bone mineral density and biochemical markers of bone turnover in Japanese postmenopausal women with osteoporosis: results from a randomized placebo-controlled trial. Osteoporos Int.
204 Fisher B, Costantino JP, Wickerham DL, et al. (1998). Tamoxifen for prevention of breast cancer: report of the National Surgical Adjuvant Breast and Bowel Project P-1 Study. J Natl Cancer Inst.
205 Chevalley T, Rizzoli R, Nydegger V, et al. (1994). Effects of calcium supplements on femoral bone mineral density and vertebral fracture rate in vitamin-D-replete elderly patients. Osteoporos Int.
206 Prince RL, Devine A, Dhaliwal SS, et al. (2006). Effects of calcium supplementation on clinical fracture and bone structure: results of a 5-year, double-blind, placebo-controlled trial in elderly women. Arch Intern Med.
207 Reid IR, Mason B, Horne A, et al. (2006). Randomized controlled trial of calcium in healthy older women. Am J Med.
208 Hansson T, Roos B. (1987). The effect of fluoride and calcium on spinal bone mineral content: a controlled, prospective (3 years) study. Calcif Tissue Int.
209 Recker RR, Hinders S, Davies KM, et al. (1996). Correcting calcium nutritional deficiency prevents spine fractures in elderly women. J Bone Miner Res.
210 Reid IR, Ames RW, Evans MC, et al. (1993). Effect of calcium supplementation on bone loss in postmenopausal women. N Engl J Med.
211 Riggs BL, O'Fallon WM, Muhs J, et al. (1998). Long-term effects of calcium supplementation on serum parathyroid hormone level, bone turnover, and bone loss in elderly women. J Bone Miner Res.
212 Nelson HD, Humphrey LL, Nygren P, et al. (2002). Postmenopausal hormone replacement therapy: scientific review. JAMA.
213 Torres A, Garcia S, Gomez A, et al. (2004). Treatment with intermittent calcitriol and calcium reduces bone loss after renal transplantation. Kidney Int.
214 Sato Y IJKTSK. Low-dose vitamin D prevents muscular atrophy and reduces falls and hip fractures in women after stroke: a randomized controlled trial. Cerebrovasc Dis 2005;20(3):187–92.
215 Adachi JD, Bensen WG, Bianchi F, et al. (1996). Vitamin D and calcium in the prevention of corticosteroid induced osteoporosis: a 3 year followup. J Rheumatol.
216 Aloia JF, Vaswani A, Ellis K, et al. (1985). A model for involutional bone loss. J Lab Clin Med.
217 Avenell A, Grant AM, McGee M, et al. (2004). The effects of an open design on trial participant recruitment, compliance and retention—a randomized controlled trial comparison with a blinded, placebo-controlled design. Clin Trials.
218 Baeksgaard L, Andersen KP, Hyldstrup L. (1998). Calcium and vitamin D supplementation increases spinal BMD in healthy, postmenopausal women. Osteoporos Int.
219 Caniggia A, Delling G, Nuti R, et al. (1984). Clinical, biochemical and histological results of a double-blind trial with 1,25-dihydroxyvitamin D3, estradiol and placebo in post-menopausal osteoporosis. Acta Vitaminol Enzymol.
220 Chapuy MC, Arlot ME, Delmas PD, et al. (1994). Effect of calcium and cholecalciferol treatment for three years on hip fractures in elderly women. BMJ.
221 Chapuy MC, Arlot ME, Duboeuf F, et al. (1992). Vitamin D3 and calcium to prevent hip fractures in the elderly women. N Engl J Med.
222 Chapuy MC, Pamphile R, Paris E, et al. (2002). Combined calcium and vitamin D3 supplementation in elderly women: confirmation of reversal of secondary hyperparathyroidism and hip fracture risk: the Decalyos II study. Osteoporos Int.
223 Dawson-Hughes B, Harris SS, Krall EA, et al. (1997). Effect of calcium and vitamin D supplementation on bone density in men and women 65 years of age or older. N Engl J Med.
224 Dukas L, Bischoff HA, Lindpaintner LS, et al. (2004). Alfacalcidol reduces the number of fallers in a community-dwelling elderly population with a minimum calcium intake of more than 500 mg daily. J Am Geriatr Soc.
225 Ebeling PR, Russell RG. (2003). Teriparatide (rhPTH 1–34) for the treatment of osteoporosis. Int J Clin Pract.
226 Gallagher JC, Riggs BL, Recker RR, et al. (1989). The effect of calcitriol on patients with postmenopausal osteoporosis with special reference to fracture frequency. Proc Soc Exp Biol Med.
227 Gallagher JC, Goldgar D. (1990). Treatment of postmenopausal osteoporosis with high doses of synthetic calcitriol. A randomized controlled study. Ann Intern Med.
228 Gorai I, Chaki O, Taguchi Y, et al. (1999). Early postmenopausal bone loss is prevented by estrogen and partially by 1alpha-OH-vitamin D3: therapeutic effects of estrogen and/or 1alpha-OH-vitamin D3. Calcif Tissue Int.
229 Grant AM, Avenell A, Campbell MK, et al. (2005). Oral vitamin D3 and calcium for secondary prevention of low-trauma fractures in elderly people (Randomised Evaluation of Calcium Or vitamin D, RECORD): a randomised placebo-controlled trial. Lancet.
230 Geusens P, Dequeker J. (1986). Long-term effect of nandrolone decanoate, 1 alpha-hydroxyvitamin D3 or intermittent calcium infusion therapy on bone mineral content, bone remodeling and fracture rate in symptomatic osteoporosis: a double-blind controlled study. Bone Miner.
231 Harwood RH, Sahota O, Gaynor K, et al. (2004). A randomised, controlled comparison of different calcium and vitamin D supplementation regimens in elderly women after hip fracture: The Nottingham Neck of Femur (NONOF) Study. Age Ageing.
232 Hayashi Y, Fujita T, Inoue T. (1992). Decrease of vertebral fracture in osteoporotics by administration of 1a-hydroxy-vitamin D_3_. Journal of Bone and Mineral Metabolism.
233 Lips P, Graafmans WC, Ooms ME, et al. (1996). Vitamin D supplementation and fracture incidence in elderly persons. A randomized, placebo-controlled clinical trial. Ann Intern Med.
234 Menczel J, Foldes J, Steinberg R, et al. Alfacalcidol (alpha D3) and calcium in osteoporosis. Clin Orthop Relat Res 1994;(300):241–7.
235 Meyer HE, Smedshaug GB, Kvaavik E, et al. (2002). Can vitamin D supplementation reduce the risk of fracture in the elderly? A randomized controlled trial. J Bone Miner Res.
236 Orimo H, Shiraki M, Hayashi T, et al. (1987). Reduced occurrence of vertebral crush fractures in senile osteoporosis treated with 1 alpha (OH)-vitamin D3. Bone Miner.
237 Orimo H, Shiraki M, Hayashi Y, et al. (1994). Effects of 1 alpha-hydroxyvitamin D3 on lumbar bone mineral density and vertebral fractures in patients with postmenopausal osteoporosis. Calcif Tissue Int.
238 Ott SM, Chesnut CH. (1989). Calcitriol treatment is not effective in postmenopausal osteoporosis. Ann Intern Med.
239 Peacock M, Liu G, Carey M, et al. (2000). Effect of calcium or 25OH vitamin D3 dietary supplementation on bone loss at the hip in men and women over the age of 60. J Clin Endocrinol Metab.
240 Pfeifer M, Begerow B, Minne HW, et al. (2000). Effects of a short-term vitamin D and calcium supplementation on body sway and secondary hyperparathyroidism in elderly women. J Bone Miner Res.
241 Sambrook P, Henderson NK, Keogh A, et al. (2000). Effect of calcitriol on bone loss after cardiac or lung transplantation. J Bone Miner Res.
242 Sato Y, Maruoka H, Oizumi K. (1997). Amelioration of hemiplegia-associated osteopenia more than 4 years after stroke by 1 alpha-hydroxyvitamin D3 and calcium supplementation. Stroke.
243 Sato Y, Manabe S, Kuno H, et al. (1999). Amelioration of osteopenia and hypovitaminosis D by 1alpha-hydroxyvitamin D3 in elderly patients with Parkinson's disease. J Neurol Neurosurg Psychiatry.
244 Sato Y, Kuno H, Kaji M, et al. (1999). Effect of ipriflavone on bone in elderly hemiplegic stroke patients with hypovitaminosis D. Am J Phys Med Rehabil.
245 Shikari M, Kushida K, Yamazaki K, et al. (1996). Effects of 2 years' treatment of osteoporosis with 1 alpha-hydroxy vitamin D3 on bone mineral density and incidence of fracture: a placebo-controlled, double-blind prospective study. Endocr J.
246 Smith H, Anderson F, Raphael H, et al. (2004). Effect of annual intramuscular vitamin D supplementation on fracture risk: population-based, randomised, double-blind, placebo-controlled trial [abstract]. Osteoporosis International.
247 Stempfle HU, Werner C, Echtler S, et al. (1999). Prevention of osteoporosis after cardiac transplantation: a prospective, longitudinal, randomized, double-blind trial with calcitriol. Transplantation.
248 Tilyard MW, Spears GF, Thomson J, et al. (1992). Treatment of postmenopausal osteoporosis with calcitriol or calcium. N Engl J Med.
249 Trivedi DP, Doll R, Khaw KT. (2003). Effect of four monthly oral vitamin D3 (cholecalciferol) supplementation on fractures and mortality in men and women living in the community: randomised double blind controlled trial. BMJ.
250 Kushida K, Fukunaga M, Kishimoto H, et al. (2004). A comparison of incidences of vertebral fracture in Japanese patients with involutional osteoporosis treated with risedronate and etidronate: a randomized, double-masked trial. Journal of Bone and Mineral Metabolism.
251 Fukunaga M, Kushida K, Kishimoto H, et al. (2002). A comparison of the effect of risedronate and etidronate on lumbar bone mineral density in Japanese patients with osteoporosis: a randomized controlled trial. Osteoporos Int.
252 Guanabens N PARIALPFCLMAMdOMRMPPRJ. Alendronate is more effective than etidronate for increasing bone mass in osteopenic patients with primary biliary cirrhosis. The American journal of gastroenterology 2003;98(10):2268–74.
253 Iwamoto J, Takeda T, Ichimura S, et al. (2003). Comparative effects of treatment with etidronate and alendronate on bone resorption, back pain, and activities of daily living in elderly women with vertebral fractures. Keio J Med.
254 Rosen CJ, Hochberg MC, Bonnick SL, et al. (2005). Treatment with once-weekly alendronate 70 mg compared with once-weekly risedronate 35 mg in women with postmenopausal osteoporosis: a randomized double-blind study. J Bone Miner Res.
255 Muscoso E, Puglisi N, Mamazza C, et al. (2004). Antiresorption therapy and reduction in fracture susceptibility in the osteoporotic elderly patient: open study. Eur Rev Med Pharmacol Sci.
256 Tauchmanova L, De Simone G, Musella T, et al. (2006). Effects of various antireabsorptive treatments on bone mineral density in hypogonadal young women after allogeneic stem cell transplantation. Bone Marrow Transplant.
257 Bonnick S, Saag KG, Kiel DP, et al. Comparison of Weekly Treatment of Postmenopausal Osteoporosis with Alendronate versus Risedronate Over Two Years. J Clin Endocrinol Metab 2006.
258 Vogel VG, Costantino JP, Wickerham DL, et al. (2006). Effects of tamoxifen vs raloxifene on the risk of developing invasive breast cancer and other disease outcomes: the NSABP Study of Tamoxifen and Raloxifene (STAR) P-2 trial. Jama.
259 Body JJ, Gaich GA, Scheele WH, et al. (2002). A randomized double-blind trial to compare the efficacy of teriparatide. J Clin Endocrinol Metab.
260 Luckey M, Kagan R, Greenspan S, et al. (2004). Once-weekly alendronate 70 mg and raloxifene 60 mg daily in the treatment of postmenopausal osteoporosis. Menopause.
261 Garcia-Delgado I PSG-FLRERJHF. Calcitonin, etidronate, and calcidiol treatment in bone loss after cardiac transplantation. Calcified tissue international 1997;60(2):155–9.
262 Recker RR, Kendler D, Recknor CP, et al. Comparative effects of raloxifene and alendronate on fracture outcomes in postmenopausal women with low bone mass. Bone 2006.
263 Boutsen Y, Jamart J, Esselinckx W, et al. (1997). Primary prevention of glucocorticoid-induced osteoporosis with intermittent intravenous pamidronate: a randomized trial. Calcif Tissue Int.
264 Uchida S, Taniguchi T, Shimizu T, et al. (2005). Therapeutic effects of alendronate 35 mg once weekly and 5 mg once daily in Japanese patients with osteoporosis: a double-blind, randomized study. J Bone Miner Metab.
265 de Nijs RN, Jacobs JW, Algra A, et al. (2004). Prevention and treatment of glucocorticoid-induced osteoporosis with active vitamin D3 analogues: a review with meta-analysis of randomized controlled trials including organ transplantation studies. Osteoporos Int.
266 Bianda T LAJGBHSHKWSC. Prevention of osteoporosis in heart transplant recipients: a comparison of calcitriol with calcitonin and pamidronate. Calcified tissue international 2000;67(2):116–21.
267 Henderson K, Eisman J, Keogh A, et al. (2001). Protective effect of short-tem calcitriol or cyclical etidronate on bone loss after cardiac or lung transplantation. Journal of bone and mineral research : the official journal of the American Society for Bone and Mineral Research.
268 Ringe JD, Dorst A, Faber H, et al. (2003). Three-monthly ibandronate bolus injection offers favourable tolerability and sustained efficacy advantage over two years in established corticosteroid-induced osteoporosis. Rheumatology (Oxford).
269 Sambrook PN, Kotowicz M, Nash P, et al. (2003). Prevention and treatment of glucocorticoid-induced osteoporosis: a comparison of calcitriol, vitamin D plus calcium, and alendronate plus calcium. J Bone Miner Res.
270 Van Cleemput J, Daenen W, Geusens P, et al. (1996). Prevention of bone loss in cardiac transplant recipients. A comparison of biphosphonates and vitamin D. Transplantation.
271 Blair MM, Carson DS, Barrington R. (2000). Bisphosphonates in the prevention and treatment of glucocorticoid-induced osteoporosis. J Fam Pract.
272 Adachi JD, Saag KG, Delmas PD, et al. (2001). Two-year effects of alendronate on bone mineral density and vertebral fracture in patients receiving glucocorticoids: a randomized, double-blind, placebo-controlled extension trial. Arthritis Rheum.
273 Wallach S, Cohen S, Reid DM, et al. (2000). Effects of risedronate treatment on bone density and vertebral fracture in patients on corticosteroid therapy. Calcif Tissue Int.
274 Adachi JD, Bensen WG, Brown J, et al. (1997). Intermittent etidronate therapy to prevent corticosteroid-induced osteoporosis. N Engl J Med.
275 Roux C, Oriente P, Laan R, et al. (1998). Randomized trial of effect of cyclical etidronate in the prevention of corticosteroid-induced bone loss. Ciblos Study Group. J Clin Endocrinol Metab.
276 Saag KG, Emkey R, Schnitzer TJ, et al. (1998). Alendronate for the prevention and treatment of glucocorticoid-induced osteoporosis. Glucocorticoid-Induced Osteoporosis Intervention Study Group. N Engl J Med.
277 Jencen D, Reid D, Devogelaer JP, et al. Risedronate is safe and well tolerated in treating corticosteroid-induced osteoporosis. 2nd Meeting of the ASBMR-IBMS; San Francisco, CA. Marathon Multimedia.
278 Skingle SJ, Moore DJ, Crisp AJ. (1997). Cyclical etidronate increases lumbar spine bone density in patients on long-term glucocorticosteroid therapy. Int J Clin Pract.
279 Jenkins EA, Walker-Bone KE, Wood A, et al. (1999). The prevention of corticosteroid-induced bone loss with intermittent cyclical etidronate. Scandinavian journal of rheumatology.
280 Geusens P, Dequeker J, Vanhoof J, et al. (1998). Cyclical etidronate increases bone density in the spine and hip of postmenopausal women receiving long term corticosteroid treatment. A double blind, randomised placebo controlled study. Ann Rheum Dis.
281 Cortet B, Hachulla E, Barton I, et al. (1999). Evaluation of the efficacy of etidronate therapy in preventing glucocorticoid-induced bone loss in patients with inflammatory rheumatic diseases. A randomized study. Rev Rhum Engl Ed.
282 Chapurlat RD, Palermo L, Ramsay P, et al. (2005). Risk of fracture among women who lose bone density during treatment with alendronate. The Fracture Intervention Trial. Osteoporos Int.
283 Agrawal S, Krueger DC, Engelke JA, et al. (2006). Between-meal risedronate does not alter bone turnover in nursing home residents. J Am Geriatr Soc.
284 Caro JJ, Ishak KJ, Huybrechts KF, et al. (2004). The impact of compliance with osteoporosis therapy on fracture rates in actual practice. Osteoporos Int.
285 Siris ES, Harris ST, Rosen CJ, et al. (2006). Adherence to bisphosphonate therapy and fracture rates in osteoporotic women: relationship to vertebral and nonvertebral fractures from 2 US claims databases. Mayo Clin Proc.
286 Huybrechts KF, Ishak KJ, Caro JJ. (2006). Assessment of compliance with osteoporosis treatment and its consequences in a managed care population. Bone.
287 Faulkner DL, Young C, Hutchins D, et al. (1998). Patient noncompliance with hormone replacement therapy: a nationwide estimate using a large prescription claims database. Menopause.
288 Weycker D, Macarios D, Edelsberg J, et al. Compliance with drug therapy for postmenopausal osteoporosis. Osteoporos Int 2006.
289 de Lusignan S, van Vlymen J, Hague N, et al. Using computers to identify non-compliant people at increased risk of osteoporotic fractures in general practice: a cross-sectional study. Osteoporos Int 2006.
290 Unson CG, Litt M, Reisine S, et al. (2006). Adherence to calcium/vitamin D and estrogen protocols among diverse older participants enrolled in a clinical trial. Contemp Clin Trials.
291 Downey TW, Foltz SH, Boccuzzi SJ, et al. (2006). Adherence and persistence associated with the pharmacologic treatment of osteoporosis in a managed care setting. South Med J.
292 Curtis JR, Westfall AO, Allison JJ, et al. Channeling and adherence with alendronate and risedronate among chronic glucocorticoid users. Osteoporos Int 2006.
293 Turbi C, Herrero-Beaumont G, Acebes JC, et al. (2004). Compliance and satisfaction with raloxifene versus alendronate for the treatment of postmenopausal osteoporosis in clinical practice: An open-label, prospective, nonrandomized, observational study. Clin Ther.
294 Hodsman AB, Lindsay R. Effects of 1–84 PTH over 1 year. j Clin Endocrinol Metab 2003.
295 Mersfelder T, Armitstead JA, Ivey MF, et al. (1999). A medication use evaluation of alendronate: compliance with administration guidelines. Pharm Pract Manag Q.
296 Tosteson AN, Grove MR, Hammond CS, et al. (2003). Early discontinuation of treatment for osteoporosis. Am J Med.
297 Rossini M, Bianchi G, Di Munno O, et al. (2006). Determinants of adherence to osteoporosis treatment in clinical practice. Osteoporos Int.
298 Segal E, Tamir A, Ish-Shalom S. (2003). Compliance of osteoporotic patients with different treatment regimens. Isr Med Assoc J.
299 Buist DS, LaCroix AZ, Black DM, et al. (2000). Inclusion of older women in randomized clinical trials: factors associated with taking study medication in the fracture intervention trial. J Am Geriatr Soc.
300 Lo JC, Pressman AR, Omar MA, et al. (2006). Persistence with weekly alendronate therapy among postmenopausal women. Osteoporos Int.
301 Steel SA, Albertazzi P, Howarth EM, et al. (2003). Factors affecting long-term adherence to hormone replacement therapy after screening for osteoporosis. Climacteric.
302 Papaioannou A, Ioannidis G, Adachi JD, et al. (2003). Adherence to bisphosphonates and hormone replacement therapy in a tertiary care setting of patients in the CANDOO database. Osteoporos Int.
303 Solomon DH, Avorn J, Katz JN, et al. (2005). Compliance with osteoporosis medications. Arch Intern Med.
304 Reynolds RF, Obermeyer CM, Walker AM, et al. (2002). The role of treatment intentions and concerns about side effects in women's decision to discontinue postmenopausal hormone therapy. Maturitas.
305 Unson CG, Siccion E, Gaztambide J, et al. (2003). Nonadherence and osteoporosis treatment preferences of older women: a qualitative study. J Womens Health (Larchmt).
306 Barrett-Connor E, Espeland MA, Greendale GA, et al. (2000). Postmenopausal hormone use following a 3-year randomized clinical trial. J Womens Health Gend Based Med.
307 Finley C, Gregg EW, Solomon LJ, et al. (2001). Disparities in hormone replacement therapy use by socioeconomic status in a primary care population. J Community Health.
308 Karakoc B, Erenus M. (1998). Compliance considerations with hormone replacement therapy. Menopause.
309 Carr AJ, Thompson PW, Cooper C. Factors associated with adherence and persistence to bisphosphonate therapy in osteoporosis: a cross-sectional survey. Osteoporos Int 2006.
310 Weiss M, Vered I, Foldes AJ, et al. (2005). Treatment preference and tolerability with alendronate once weekly over a 3-month period: an Israeli multi-center study. Aging Clin Exp Res.
311 Simon JA, Lewiecki EM, Smith ME, et al. (2002). Patient preference for once-weekly alendronate 70 mg versus once-daily alendronate 10 mg: a multicenter, randomized, open-label, crossover study. Clin Ther.
312 Cramer JA, Amonkar MM, Hebborn A, et al. (2005). Compliance and persistence with bisphosphonate dosing regimens among women with postmenopausal osteoporosis. Curr Med Res Opin.
313 Brankin E, Walker M, Lynch N, et al. (2006). The impact of dosing frequency on compliance and persistence with bisphosphonates among postmenopausal women in the UK: evidence from three databases. Curr Med Res Opin.
314 Recker RR, Gallagher R, MacCosbe PE. (2005). Effect of dosing frequency on bisphosphonate medication adherence in a large longitudinal cohort of women. Mayo Clin Proc.
315 Cooper A, Drake J, Brankin E. (2006). Treatment persistence with once-monthly ibandronate and patient support vs. once-weekly alendronate: results from the PERSIST study. Int J Clin Pract.
316 Effects of estrogen or estrogen/progestin regimens on heart disease risk factors in postmenopausal women. The Postmenopausal Estrogen/Progestin Interventions (PEPI) Trial. The Writing Group for the PEPI Trial. JAMA 1995;273(3):199–208.
317 Clowes JA, Peel NF, Eastell R. (2004). The impact of monitoring on adherence and persistence with antiresorptive treatment for postmenopausal osteoporosis: a randomized controlled trial. J Clin Endocrinol Metab.
318 Chailurkit LO, Jongjaroenprasert W, Rungbunnapun S, et al. (2003). Effect of alendronate on bone mineral density and bone turnover in Thai postmenopausal osteoporosis. Journal of bone and mineral metabolism.
319 Palomba S, Orio F, Colao A, et al. (2002). Effect of estrogen replacement plus low-dose alendronate treatment on bone density in surgically postmenopausal women with osteoporosis. J Clin Endocrinol Metab.
320 Adami S, Baroni MC, Broggini M, et al. (1993). Treatment of postmenopausal osteoporosis with continuous daily oral alendronate in comparison with either placebo or intranasal salmon calcitonin. Osteoporos Int.
321 Storm T, Kollerup G, Thamsborg G, et al. (1996). Five years of clinical experience with intermittent cyclical etidronate for postmenopausal osteoporosis. J Rheumatol.
322 Zegels B, Eastell R, Russell RG, et al. (2001). Effect of high doses of oral risedronate (20 mg/day) on serum parathyroid hormone levels and urinary collagen cross-link excretion in postmenopausal women with spinal osteoporosis. Bone.
323 Cummings SR, Schwartz AV, Black DM. (2007). Alendronate and atrial fibrillation. N Engl J Med.
324 Ryan PJ, Blake GM, Davie M, et al. (2000). Intermittent oral disodium pamidronate in established osteoporosis: a 2 year double-masked placebo-controlled study of efficacy and safety. Osteoporosis international : a journal established as result of cooperation between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
325 Michalska D, Stepan JJ, Basson BR, et al. (2006). The effect of raloxifene after discontinuation of long-term alendronate treatment of postmenopausal osteoporosis. J Clin Endocrinol Metab.
326 Heath DA, Bullivant BG, Boiven C, et al. (2000). The effects of cyclical etidronate on early postmenopausal bone loss: an open, randomized controlled study. J Clin Densitom.
327 Brumsen C, Papapoulos SE, Lips P, et al. (2002). Daily oral pamidronate in women and men with osteoporosis: a 3-year randomized placebo-controlled clinical trial with a 2-year open extension. J Bone Miner Res.
328 van Staa T, Abenhaim L, Cooper C. (1997). Upper gastrointestinal adverse events and cyclical etidronate. Am J Med.
329 Sato Y, Asoh T, Kaji M, et al. (2000). Beneficial effect of intermittent cyclical etidronate therapy in hemiplegic patients following an acute stroke. Journal of bone and mineral research : the official journal of the American Society for Bone and Mineral Research.
330 McClung MR, Wasnich RD, Recker R, et al. (2004). Oral daily ibandronate prevents bone loss in early postmenopausal women without osteoporosis. J Bone Miner Res.
331 Adami S, Bruni V, Bianchini D, et al. (2000). Prevention of early postmenopausal bone loss with cyclical etidronate. J Endocrinol Invest.
332 Pitt P, Li F, Todd P, et al. (1998). A double blind placebo controlled study to determine the effects of intermittent cyclical etidronate on bone mineral density in patients on long-term oral corticosteroid treatment. Thorax.
333 Silberstein EB, Schnur W. (1992). Cyclic oral phosphate and etidronate increase femoral and lumbar bone mineral density and reduce lumbar spine fracture rate over three years. J Nucl Med.
334 Geusens P, Vanhoof JSR, Joly J, et al. (1997). Cyclic etidronate increases bone density in the spine and hip in postmenopausal women on chronic corticosteroid treatment. A double-blind controlled study. Bone.
335 Reid IR, King AR, Alexander CJ, et al. (1988). Prevention of steroid-induced osteoporosis with (3-amino-1-hydroxypropylidene)-1,1-bisphosphonate (APD). Lancet.
336 Lees B, Garland SW, Walton C, et al. (1996). Role of oral pamidronate in preventing bone loss in postmenopausal women. Osteoporosis international : a journal established as result of cooperation between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
337 Lufkin EG ARWMCAWVEKOWRB. Pamidronate: an unrecognized problem in gastrointestinal tolerability. Osteoporosis international : a journal established as result of cooperation between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA 1994;4(6):320–2.
338 Cortet B, Bera-Louville A, Gauthier P, et al. (2001). Comparative efficacy and safety study of etidronate and alendronate in postmenopausal osteoporosis. effect of adding hormone replacement therapy. Joint Bone Spine.
339 Sahota O, Fowler I, Blackwell PJ, et al. (2000). A comparison of continuous alendronate, cyclical alendronate and cyclical etidronate with calcitriol in the treatment of postmenopausal vertebral osteoporosis: a randomized controlled trial. Osteoporosis international : a journal established as result of cooperation between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
340 Downs RW, Bell NH, Ettinger MP, et al. (2000). Comparison of alendronate and intranasal calcitonin for treatment of osteoporosis in postmenopausal women. J Clin Endocrinol Metab.
341 El-Agroudy AE, El-Husseini AA, El-Sayed M, et al. (2005). A prospective randomized study for prevention of postrenal transplantation bone loss. Kidney Int.
342 Evio S, Tiitinen A, Laitinen K, et al. (2004). Effects of alendronate and hormone replacement therapy, alone and in combination, on bone mass and markers of bone turnover in elderly women with osteoporosis. J Clin Endocrinol Metab.
343 Tiras MB, Noyan V, Yildiz A, et al. (2000). Effects of alendronate and hormone replacement therapy, alone or in combination, on bone mass in postmenopausal women with osteoporosis: a prospective, randomized study. Hum Reprod.
344 Miller PD, Watts NB, Licata AA, et al. (1997). Cyclical etidronate in the treatment of postmenopausal osteoporosis: efficacy and safety after seven years of treatment. Am J Med.
345 Wimalawansa SJ. (1995). Combined therapy with estrogen and etidronate has an additive effect on bone mineral density in the hip and vertebrae: four-year randomized study. Am J Med.
346 Struys A, Snelder AA, Mulder H. (1995). Cyclical etidronate reverses bone loss of the spine and proximal femur in patients with established corticosteroid-induced osteoporosis. Am J Med.
347 Hasling C, Charles P, Jensen FT, et al. (1994). A comparison of the effects of oestrogen/progestogen, high-dose oral calcium, intermittent cyclic etidronate and an ADFR regime on calcium kinetics and bone mass in postmenopausal women with spinal osteoporosis. Osteoporos Int.
348 Evans RA, Somers NM, Dunstan CR, et al. (1993). The effect of low-dose cyclical etidronate and calcium on bone mass in early postmenopausal women. Osteoporos Int.
349 Ringe JD, Faber H, Farahmand P, et al. (2006). Efficacy of risedronate in men with primary and secondary osteoporosis: results of a 1-year study. Rheumatol Int.
350 Henderson S, Hoffman N, Prince R. (2006). A double-blind placebo-controlled study of the effects of the bisphosphonate risedronate on bone mass in patients with inflammatory bowel disease. Am J Gastroenterol.
351 Tauchmanova L, Selleri C, Esposito M, et al. (2003). Beneficial treatment with risedronate in long-term survivors after allogeneic stem cell transplantation for hematological malignancies. Osteoporos Int.
352 Shiraki M, Fukunaga M, Kushida K, et al. (2003). A double-blind dose-ranging study of risedronate in Japanese patients with osteoporosis (a study by the Risedronate Late Phase II Research Group). Osteoporos Int.
353 Smith MR, Eastham J, Gleason DM, et al. (2003). Randomized controlled trial of zoledronic acid to prevent bone loss in men receiving androgen deprivation therapy for nonmetastatic prostate cancer. The Journal of urology.
354 McClung MR, San Martin J, Miller PD, et al. (2005). Opposite bone remodeling effects of teriparatide and alendronate in increasing bone mass. Arch Intern Med.
355 Grady D, Ettinger B, Moscarelli E, et al. (2004). Safety and adverse effects associated with raloxifene: multiple outcomes of raloxifene evaluation. Obstet Gynecol.
356 Ensrud K, Genazzani AR, Geiger MJ, et al. (2006). Effect of raloxifene on cardiovascular adverse events in postmenopausal women with osteoporosis. Am J Cardiol.
357 Liu JL, Zhu HM, Huang QR, et al. (2004). Effects of raloxifene hydrochloride on bone mineral density, bone metabolism and serum lipids in Chinese postmenopausal women with osteoporosis: a multi-center, randomized, placebo-controlled clinical trial. Chin Med J (Engl).
358 Zheng S, Wu Y, Zhang Z, et al. (2003). Effects of raloxifene hydrochloride on bone mineral density, bone metabolism and serum lipids in postmenopausal women: a randomized clinical trial in Beijing. Chin Med J (Engl).
359 Smith MR, Fallon MA, Lee H, et al. (2004). Raloxifene to prevent gonadotropin-releasing hormone agonist-induced bone loss in men with prostate cancer: a randomized controlled trial. The Journal of clinical endocrinology and metabolism.
360 Johnston CC, Bjarnason NH, Cohen FJ, et al. (2000). Long-term effects of raloxifene on bone mineral density, bone turnover, and serum lipid levels in early postmenopausal women: three-year data from 2 double-blind, randomized, placebo-controlled trials. Arch Intern Med.
361 Meunier PJ, Vignot E, Garnero P, et al. (1999). Treatment of postmenopausal women with osteoporosis or low bone density with raloxifene. Raloxifene Study Group. Osteoporos Int.
362 Kung AW, Chao HT, Huang KE, et al. (2003). Efficacy and safety of raloxifene 60 milligrams/day in postmenopausal Asian women. J Clin Endocrinol Metab.
363 Kristensen B, Ejlertsen B, Dalgaard P, et al. (1994). Tamoxifen and bone metabolism in postmenopausal low-risk breast cancer patients: a randomized study. Journal of clinical oncology : official journal of the American Society of Clinical Oncology.
364 Love RR, Mazess RB, Barden HS, et al. (1992). Effects of tamoxifen on bone mineral density in postmenopausal women with breast cancer. N Engl J Med.
365 Johnell O, Scheele WH, Lu Y, et al. (2002). Additive effects of raloxifene and alendronate on bone density and biochemical markers of bone remodeling in postmenopausal women with osteoporosis. J Clin Endocrinol Metab.
366 Grey AB, Stapleton JP, Evans MC, et al. (1995). The effect of the antiestrogen tamoxifen on bone mineral density in normal late postmenopausal women. Am J Med.
367 Draper MW, Flowers DE, Huster WJ, et al. (1996). A controlled trial of raloxifene (LY139481) HCl: impact on bone turnover and serum lipid profile in healthy postmenopausal women. J Bone Miner Res.
368 Neven P, Lunde T, Benedetti-Panici P, et al. (2003). A multicentre randomised trial to compare uterine safety of raloxifene with a continuous combined hormone replacement therapy containing oestradiol and norethisterone acetate. BJOG.
369 Decensi A, Robertson C, Viale G, et al. (2003). A randomized trial of low-dose tamoxifen on breast cancer proliferation and blood estrogenic biomarkers. Journal of the National Cancer Institute.
370 Cherry N, Gilmour K, Hannaford P, et al. (2002). Oestrogen therapy for prevention of reinfarction in postmenopausal women: a randomised placebo controlled trial. Lancet.
371 Hulley S, Grady D, Bush T, et al. (1998). Randomized trial of estrogen plus progestin for secondary prevention of coronary heart disease in postmenopausal women. Heart and Estrogen/progestin Replacement Study (HERS) Research Group. JAMA.
372 Notelovitz M, John VA, Good WR. (2002). Effectiveness of Alora estradiol matrix transdermal delivery system in improving lumbar bone mineral density in healthy, postmenopausal women. Menopause.
373 Stefanick ML, Anderson GL, Margolis KL, et al. (2006). Effects of conjugated equine estrogens on breast cancer and mammography screening in postmenopausal women with hysterectomy. JAMA.
374 Miller RG. (1969). The treatment of osteoporosis. A report of a double blind clinical therapeutic trial. Gerontol Clin (Basel).
375 Greenwald MW, Gluck OS, Lang E, et al. (2005). Oral hormone therapy with 17beta-estradiol and 17beta-estradiol in combination with norethindrone acetate in the prevention of bone loss in early postmenopausal women: dose-dependent effects. Menopause.
376 Freedman M, San Martin J, O'Gorman J, et al. (2001). Digitized mammography: a clinical trial of postmenopausal women randomly assigned to receive raloxifene, estrogen, or placebo. J Natl Cancer Inst.
377 Frediani B, Allegri A, Bisogno S, et al. (1998). Effects of combined treatment with calcitriol plus alendronate on bone mass and bone turnover in postmenopausal osteoporosis: Two years of continuous treatment. Clinical Drug Investigation.
378 Peichl P, Marteau R, Griesmacher A, et al. (2005). Salmon calcitonin nasal spray treatment for postmenopausal women after hip fracture with total hip arthroplasty. J Bone Miner Metab.
379 Amory JK, Watts NB, Easley KA, et al. (2004). Exogenous testosterone or testosterone with finasteride increases bone mineral density in older men with low serum testosterone. The Journal of clinical endocrinology and metabolism.
380 Kotaniemi A, Piirainen H, Paimela L, et al. (1996). Is continuous intranasal salmon calcitonin effective in treating axial bone loss in patients with active rheumatoid arthritis receiving low dose glucocorticoid therapy?. J Rheumatol.
381 Snyder PJ, Peachey H, Hannoush P, et al. (1999). Effect of testosterone treatment on bone mineral density in men over 65 years of age. J Clin Endocrinol Metab.
382 Orwoll ES, Scheele WH, Paul S, et al. (2003). The effect of teriparatide. J Bone Miner Res.
383 Lyritis GP, Ioannidis GV, Karachalios T, et al. (1999). Analgesic effect of salmon calcitonin suppositories in patients with acute pain due to recent osteoporotic vertebral crush fractures: a prospective double-blind, randomized, placebo-controlled clinical study. The Clinical journal of pain.
384 Reginster JY, Deroisy R, Lecart MP, et al. (1995). A double-blind, placebo-controlled, dose-finding trial of intermittent nasal salmon calcitonin for prevention of postmenopausal lumbar spine bone loss. Am J Med.
385 Abellan PM, Bayina GFJ, Calabozo M, et al. (1995). Multicentric comparative study of synthetic salmon calcitonin nasally administered in the treatment of established postmenopausic osteoporosis. Anales De Medicina Interna.
386 Sambrook P, Birmingham J, Kelly P, et al. (1993). Prevention of corticosteroid osteoporosis. A comparison of calcium, calcitriol, and calcitonin. N Engl J Med.
387 Reginster JY, Denis D, Albert A, et al. (1987). 1-Year controlled randomised trial of prevention of early postmenopausal bone loss by intranasal calcitonin. Lancet.
388 Gnudi S, Mongiorgi R, Moroni A, et al. (1988). Densitometric analysis in in vivo evaluation of synthetic salmon calcitonin activity. J Clin Pharm Ther.
389 Kung AW, Pasion EG, Sofiyan M, et al. (2006). A comparison of teriparatide and calcitonin therapy in postmenopausal Asian women with osteoporosis: a 6-month study. Curr Med Res Opin.
390 Hwang JS, Tu ST, Yang TS, et al. (2006). Teriparatide vs. calcitonin in the treatment of Asian postmenopausal women with established osteoporosis. Osteoporos Int.
391 Huusko TM, Karppi P, Kautiainen H, et al. (2002). Randomized, double-blind, clinically controlled trial of intranasal calcitonin treatment in patients with hip fracture. Calcif Tissue Int.
392 Flicker L, Hopper JL, Larkins RG, et al. (1997). Nandrolone decanoate and intranasal calcitonin as therapy in established osteoporosis. Osteoporosis international : a journal established as result of cooperation between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
393 Adachi JD, Bensen WG, Bell MJ, et al. (1997). Salmon calcitonin nasal spray in the prevention of corticosteroid-induced osteoporosis. Br J Rheumatol.
394 Kenny AM, Prestwood KM, Gruman CA, et al. (2001). Effects of transdermal testosterone on bone and muscle in older men with low bioavailable testosterone levels. The journals of gerontology Series A, Biological sciences and medical sciences.
395 Howell SJ, Radford JA, Adams JE, et al. (2001). Randomized placebo-controlled trial of testosterone replacement in men with mild Leydig cell insufficiency following cytotoxic chemotherapy. Clinical Endocrinology.
396 McCullough ML, Rodriguez C, Diver WR, et al. (2005). Dairy, calcium, and vitamin D intake and postmenopausal breast cancer risk in the Cancer Preventino Study II Nutrition Cohort. Cancer Epidemiol Biomarkers Prev.
397 Tseng M, Breslow RA, Graubard BI, et al. (2005). Dairy, calcium, and vitamin D intake and prostate cancer risk in the National Health and Nutrition Examination Epidemiologic Follow-up Study cohort. Am J Clin Nutr.
398 Lieberman DA, Prindiville S, Weiss DG, et al. (2003). Risk factors for advance colonic neoplasia and hyperplastic polyps in asymptomatic individuals. JAMA.
399 Wu K, Willett WC, Fuchs CS, et al. (2002). Calcium intake and risk of colon cancer in women and men. J Natl Cancer Inst.
400 Jarvinen R, Knekt P, Hakulinen T, et al. (2001). Prospective study on milk products, calcium and cancers of the colon and rectum. Eur J Clin Nutr.
401 Sellers TA, Bazyk AE, Bostick RM, et al. (1998). Diet and risk of colon cancer in a large prospective study of older women: an analysis stratified on family history (Iowa, United States). Cancer Causes Control.
402 Kampman E, Goldbohm RA, van den Brandt PA, et al. (1994). Fermented dairy products, calcium, and colorectal cancer in The Netherlands Cohort Study. Cancer Res.
403 Stemmermann GN, Nomura A, Chyou PH. (1990). The influence of dairy and nondairy calcium on subsite large-bowel cancer risk. Dis Colon Rectum.
404 Paganini-Hill A. (1999). Estrogen replacement therapy and colorectal cancer risk in elderly women. Dis Colon Rectum.
405 Fernandez E, La Vecchia C, Braga C, et al. (1998). Hormone replacement therapy and risk of colon and rectal cancer. Cancer Epidemiol Biomarkers Prev.
406 Calle EE, Miracle-McMahill HL, Thun MJ, et al. (1995). Estrogen replacement therapy and risk of fatal colon cancer in a prospective cohort of postmenopausal women. J Natl Cancer Inst.
407 Risch HA, Howe GR. (1995). Menopausal hormone use and colorectal cancer in Saskatchewan: a record linkage cohort study. Cancer Epidemiol Biomarkers Prev.
408 Bischoff-Ferrari HA, Dawson-Hughes B, Willett WC, et al. (2004). Effect of Vitamin D on falls: a meta-analysis. JAMA.
409 Pickney CS, Arnason JA. (2005). Correlation between patient recall of bone densitometry results and subsequent treatment adherence. Osteoporos Int.
410 Robbins B, Rausch KJ, Garcia RI, et al. (2004). Multicultural medication adherence: a comparative study. J Gerontol Nurs.
411 Guilera M, Fuentes M, Grifols M, et al. (2006). Does an educational leaflet improve self-reported adherence to therapy in osteoporosis? The OPTIMA study. Osteoporos Int.