# Results

## Introduction

In what follows, we begin by describing the results of our literature searches. We then provide a brief description of the included studies. The remainder of the chapter is organized by Key Question (KQ). Under each of the six KQs, we begin by listing the key points of the findings, followed by a brief description of included studies and a detailed synthesis of the evidence. The detailed syntheses are organized first by treatment comparison and then by outcome. We conducted quantitative syntheses where possible, as described in the Methods chapter.

A list of abbreviations and acronyms used in this chapter is provided at the end of the report.

## Results of Literature Searches

Figure 3 depicts the flow of articles through the literature search and screening process. Searches of PubMed^®^, Embase^®^, and CDSR yielded 8,103 unique citations. Manual searching of grey literature databases, bibliographies of key articles, and information received through requests for scientific information packets identified 224 additional citations, for a total of 8,327 citations. After applying inclusion/exclusion criteria at the title-and-abstract level, 505 full-text articles were retrieved and screened. Of these, 323 were excluded at the full-text screening stage, leaving 182 articles for data abstraction. These 182 articles described 148 unique studies. The relationship of studies to the review questions is as follows: 14 studies relevant to KQ 1, 3 studies relevant to KQ 2, 6 studies relevant to KQ 3, 42 studies relevant to KQ 4, 83 studies relevant to KQ 5, and 14 studies relevant to KQ 6 (some studies were relevant to more than one KQ).

Figure 3 Literature flow diagram

^a^ Some studies were relevant to more than one KQ.

Abbreviations: CRT=cardiac resynchronization therapy; KQ=Key Question; RCT=randomized controlled trial

This figure depicts the flow of articles through the literature search and screening process. Searches of PubMed®, Embase®, and the Cochrane Database of Systematic Reviews yielded 8,103 unique citations. Manual searching identified 224 additional citations, for a total of 8,327 citations. After applying inclusion/exclusion criteria at the title-and-abstract level, 505 full-text articles were retrieved and screened. Of these, 323 were excluded at the full-text screening stage, leaving 182 articles (representing 148 unique studies) for data abstraction. Many included articles/studies were relevant to more than one KQ. Totals included for each KQ were: 14 studies for KQ 1; 3 studies for KQ 2; 6 studies for KQ 3; 42 studies for KQ 4; 83 studies for KQ 5; and 14 studies for KQ 6.

Appendix C provides a detailed listing of included articles. Appendix D provides a complete list of articles excluded at the full-text screening stage, with reasons for exclusion. Appendix E provides a “study key” table listing the primary and companion publications for the 148 included studies.

## Description of Included Studies

Overall, we included 148 studies represented by 182 publications: 14 studies were relevant to KQ 1, 3 studies to KQ 2, 6 studies to KQ 3, 42 studies to KQ 4, 83 studies to KQ 5, and 14 studies to KQ 6. Studies were conducted wholly or partly in continental Europe (57%), the United States or Canada (22%), the UK (10%), Asia (9%), South America (5%), Australia or New Zealand (3%), and other locations (7%). Further details on the studies included for each KQ are provided in the relevant results sections, below, and in Appendix F.

We searched the ClinicalTrials.gov registry of clinical studies as a mechanism for ascertaining publication bias by identifying studies that have been completed but are as yet unpublished. We acknowledge that this is not an exhaustive strategy, as several other registries also exist with differing geographical focus and varying degrees of overlap in their trial listings; however, in the opinion of the investigators, the widely used, U.S.-based ClinicalTrials.gov registry provided the most relevant information to the populations and interventions of interest in this review. Our search yielded 610 trial records; a single reviewer identified 77 of these records as potentially relevant to the review. Of these 77 records, 34 had expected completion dates 1 year or more prior to our search. From that group of 34 trials, we identified publications for 23. Of the remaining 11 trials for which we did not identify publications, 1 was considered potentially relevant to KQ 1, and 10 were potentially relevant to KQ 5.

The one unpublished study potentially relevant to KQ 1 was designed to compare the effects of metoprolol, verapamil, diltiazem, and carvedilol on ventricular rate, working capacity, and quality of life in 80 patients. In comparison, the 14 studies relevant to KQ 1 included in this review provide data for 1,017 patients.

Of the 10 unpublished studies potentially relevant to KQ 5, 8 addressed procedural interventions and 2 compared procedural interventions with medical management. One of the completed studies represents the pilot portion of the Catheter Ablation versus Antiarrhythmic Drug Therapy for Atrial Fibrillation (CABANA) trial, which has now moved forward to begin the full-scale trial phase of 3,000 patients comparing ablation to pharmacological therapies for rate and/or rhythm control. In total, data from these 10 unpublished trials could potentially provide additional evidence on the comparative safety and effectiveness of rhythm-control procedures for up to 1,374 patients. By contrast, 83 studies included for KQ 5 involved 11,014 patients.

In summary, because of the relatively low proportion of unpublished studies identified through our ClinicalTrials.gov registry analysis, we do not believe these findings indicate significant publication bias in the evidence base that would impact our overall conclusions.

## Key Question 1 Rate-Control Drugs

KQ 1. What are the comparative safety and effectiveness of pharmacological agents used for ventricular rate control in patients with atrial fibrillation? Do the comparative safety and effectiveness of these therapies differ among specific patient subgroups of interest?

### Key Points

- Based on 3 studies (2 good, 1 fair quality) involving 271 patients, evidence suggests that amiodarone is comparable to the calcium channel blocker diltiazem for rate control (low strength of evidence).
- Based on 3 studies (2 good, 1 fair quality) involving 390 patients, evidence suggests that amiodarone provides better rate control than digoxin (low strength of evidence).
- Based on 4 studies (1 good, 3 fair quality) involving 422 patients, evidence suggests that the calcium channel blockers verapamil and diltiazem provide better rate control than digoxin (high strength of evidence).
- Many outcomes/comparisons were rated to have insufficient strength of evidence. These include improvement of AF symptoms in patients receiving combined treatment with carvedilol plus digoxin compared with digoxin alone, rate control in patients using metoprolol versus diltiazem or sotalol, and the safety of any one pharmacological agent used for ventricular rate control in patients with AF.
- Data are also insufficient as to whether the safety and effectiveness of these therapies differ among specific patient subgroups of interest.
- Included studies focused on the control of ventricular rate as the outcome of interest; there was no evidence as to the safety and effectiveness of therapies on final outcomes.

### Description of Included Studies

A total of 14 RCTs involving 1,017 patients were identified that assessed the use of pharmacological agents for ventricular rate control in patients with AF (Appendix Table F-1). Six studies were considered to be of good quality,138-143 eight of fair quality,144-151 and none of poor quality. Thirteen studies were published between 2000 and 2006, and one143 was published in 2009. Four studies were multicenter145,147,148,150 and 10 were single-center.138-144,146,149,151 Only one study included a site in the United States;151 eight included sites in Europe,138-140,142,144-147 two included sites in Asia,143,150 and one each included sites in Canada,148 the UK,141 and Australia/New Zealand.149 The study population consisted entirely of patients with persistent AF in four studies,141,144,145,147 and entirely of patients with paroxysmal AF in one study.143 Funding was unclear or not reported in 10 studies.138-140,142-144,146-148,151 A total of three studies included funding from industry,141,145,150 two received funding from nongovernment/nonindustry sources,145,149 and no studies were government-only funded. In eight studies the setting was inpatient: five of these were in emergency rooms,139,143,148,149,151 and the other three did not include emergency room patients.138,140,144 In the remaining studies, five were classified as outpatient,141,142,146,147,150 and in one the setting was unclear.145 Mean age varied from 63–71.5 years. Most of the studies included patients with no history of heart failure, and the mean ejection fraction varied from 23.7–66 percent. Only a few studies included patients with coronary artery disease.

Figure 4 represents the treatment comparisons evaluated for this KQ.

Figure 4 Overview of treatment comparisons evaluated for KQ 1^a^ a Lines running from one oval back to the same oval (e.g., “Beta Blockers” oval) indicate intraclass comparisons (e.g., comparison of one beta blocker drug with another). Numbers refer to numbers of comparisons.

Abbreviation: KQ=Key Question

This figure shows the number of direct comparisons between treatments evaluated in KQ 1. Two studies compared beta blockers to digoxin, one compared beta blockers to calcium channel blockers and one compared beta blockers to calcium channel blockers in patients using digoxin. One study compared two beta blockers (sotalol and metoprolol) in patients receiving digoxin. Amiodarone was compared to calcium channel blockers in three studies, and to digoxin in three. One study compared the benefits of adding calcium channel blockers to digoxin compared to digoxin alone, and three studies compared calcium channel blockers to digoxin. Finally, one study compared clonidine, digoxin, and calcium channel blockers.

Two studies compared beta blockers with digoxin,141,146 one compared beta blockers with calcium channel blockers,139 and one compared beta blockers with calcium channel blockers in patients using digoxin.150 One study compared two beta blockers (sotalol and metoprolol) in patients receiving digoxin.142 Amiodarone was compared with calcium channel blockers in three studies,138,143,144 and with digoxin in three.140,143,149 One study evaluated the benefits of adding calcium channel blockers to digoxin compared with digoxin alone,151 and four studies compared calcium channel blockers with digoxin.143,145,147,148 Note that although amiodarone and sotalol are evaluated under this KQ for their rate-controlling potential, these agents are also potent membrane-active, type III antiarrhythmics, thereby having potential rhythm-control benefits (and risks).

The primary outcome reported for this KQ, assessed in all but one study,150 was control of ventricular rate.

### Detailed Synthesis

#### Beta Blockers Versus Digoxin

One study compared the beta blocker carvedilol with digoxin in patients with AF and heart failure.141 The mean ejection fraction was 24 percent, and the study duration was 6 months. The combination of digoxin plus carvedilol was superior to digoxin alone for rate control at 4 months (65.2 bpm vs. 74.9 bpm; p<0.0001). After 4 months, digoxin was stopped in the combined arm and carvedilol alone was compared with digoxin alone. At 6 months, there was no difference in rate control between digoxin alone and carvedilol alone (75.7 bpm vs. 88.8 bpm; p=0.13). The combination of carvedilol plus digoxin reduced the heart rate through steady-state exercise when compared with digoxin alone (106 bpm vs. 123 bpm; p<0.05). Carvedilol alone and digoxin alone were equally effective in controlling heart rate during exercise. Digoxin was more effective than carvedilol in reducing nocturnal heart rate. The improvement of AF symptoms was greater in patients receiving combined treatment with carvedilol plus digoxin than in patients receiving digoxin alone. Three patients receiving carvedilol withdrew from the study due to gastrointestinal disturbance, tiredness, and bronchospasm.

Another study compared the beta blocker sotalol with digoxin in patients with AF at rest and during exercise.146 The heart rate at rest and at 10 minutes after exercise did not differ between the three groups (sotalol alone, digoxin alone, or combination of digoxin plus sotalol). However, the heart rate during maximal exercise was significantly lower in patients receiving sotalol (either alone or in combination with digoxin) than in patients receiving digoxin alone (p<0.01 and p<0.01, respectively) suggesting that further study of the impact of sotalol on heart rate may be needed. The heterogeneity in agents, study duration, and findings led us to conclude that the evidence was insufficient to support conclusions about the comparative effectiveness of beta blockers versus digoxin for ventricular rate control.

#### Beta Blockers Versus Calcium Channel Blockers

The beta blocker metoprolol was compared with the calcium channel blocker diltiazem in patients with AF who presented at the emergency room with heart rate ≥120 bpm in one study.139 The success rate of ventricular rate control (defined as ventricular rate <100 bpm or decrease in ventricular rate by 20% from baseline and at least less than 120 bpm or conversion to sinus rhythm) at 20 minutes was similar between patients receiving diltiazem and metoprolol (90% vs. 80%; p>0.05). However, the success rate of ventricular control at 2 minutes was greater in patients receiving diltiazem than in patients receiving metoprolol (50% vs. 15%; p<0.05). The mean percentage decrease in ventricular rate at 2, 5, 10, 15, and 20 minutes were all greater in patients receiving diltiazem (25.6, 30.7, 33.6, 34.5, and 35.9) than in patients receiving metoprolol (17.5, 20.4, 24.3, 25.9, and 28.9). There was no significant difference between the two treatment groups in the decrease of blood pressure, and none of the patients developed hypotension. The small size and quality of the one study, as well as the imprecision of the findings, led us to conclude that the evidence was insufficient to support conclusions about the comparative effectiveness of beta blockers versus calcium channel blockers for ventricular rate control (insufficient strength of evidence)

#### Beta Blockers Versus Calcium Channel Blockers in Patients Taking Digoxin

One study compared beta blockers (bisoprolol, atenolol, or metoprolol) with the calcium channel blocker verapamil in patients with chronic AF taking digoxin.150 Two-thirds of the patients using beta blockers were using bisoprolol. When compared with digoxin, beta blockers increased the minimum heart rate and decreased the maximum heart rate (although the changes did not reach statistical significance in either case [p<0.1]) and overall did not change the mean heart rate. Verapamil significantly increased the minimum heart rate and mean heart rate when compared with digoxin. Verapamil prolonged exercise duration when compared with digoxin (p<0.05), whereas beta blockers did not. Beta blockers did not affect quality of life scores (Medical Outcomes Study 36-Item Short Form Health Survey [SF-36]) when compared with digoxin. Verapamil, however, improved the role function-physical score on the SF-36 and the variety and frequency of AF symptoms when compared with digoxin. This one study included only 29 patients and was considered to provide insufficient evidence of these conclusions.

#### Sotalol Versus Metoprolol in Patients Taking Digoxin

One study compared two beta blockers (metoprolol versus sotalol) in patients with chronic AF receiving digoxin.142 Both beta blocker agents were effective at reducing heart rate at 24 hours. Patients receiving sotalol presented a lower mean heart rate at submaximal exercise than patients receiving metoprolol (116 vs. 125 bpm; p<0.001; insufficient strength of evidence). During isometric exercise, similar results were seen where sotalol produced a lower mean maximum heart rate than did metoprolol (113 vs. 129 bpm). Finally, patients receiving sotalol presented a lower mean heart rate than patients receiving metoprolol during the daytime. The QT interval in patients receiving sotalol was longer than in patients receiving metoprolol (p<0.001), but no clinical side effects or adverse outcomes were reported or associated with the use of sotalol.

#### Amiodarone Versus Calcium Channel Blockers

Three studies compared amiodarone with calcium channel blockers.138,143,144 In the first,144 both amiodarone and diltiazem significantly reduced the ventricular rate and mean heart rate from baseline to 1 month prior to cardioversion; however, there was no comparison between study arms. In the second study,138 ventricular rate was compared in patients receiving diltiazem (25 mg IV bolus followed by continuous infusion for 24 hours) and amiodarone for 15 minutes (300 mg in bolus only) and 24 hours (300 mg bolus followed by continuous infusion for 24 hours). The number of patients with >30 percent reduction in heart rate within 4 hours was similar across the three arms (14, 11, and 15, respectively; p=0.38). However, the number of patients with a heart rate less than 120 bpm within 4 hours was significantly higher in patients receiving amiodarone in both arms (9 and 1, respectively) when compared with patients receiving diltiazem (0; p=0.00016). In the third study, sustained ventricular rate control (<90 bpm) within 24 hours was compared between patients receiving diltiazem or amiodarone.143 In contrast to the other two studies, patients receiving diltiazem in this third study were more likely to achieve sustained heart rate control (90%) when compared with patients receiving amiodarone (74%; p=0.047). The median time to ventricular rate control was also significantly shorter in patients receiving diltiazem (3 hours) than in patients receiving amiodarone (7 hours; p<0.0001). Patients receiving diltiazem had lower mean ventricular rate after the first hour of drug administration compared with patients receiving amiodarone (p<0.05). Based on these three studies, amiodarone was comparable to the calcium channel blocker diltiazem for rate control, but given the inconsistency and imprecision of these findings, the strength of evidence was reduced (low strength of evidence).

#### Amiodarone Versus Digoxin

Three studies compared amiodarone with digoxin.140,143,149 In one,149 the ventricular heart rate control (<100 bpm) was significantly better with amiodarone than with digoxin at 30 minutes and 3 hours (p=0.02 and p=0.02, respectively). In the second study,140 the mean heart rate at 30 minutes was significantly lower in patients receiving amiodarone than in patients receiving digoxin (104 vs. 116 bpm, respectively; p=0.02). Similar results were seen at 60 minutes (94 versus 105 bpm, respectively; p=0.03). In the third study, sustained ventricular rate (<90 bpm) within 24 hours was compared between patients receiving digoxin or amiodarone.143 There was no difference in sustained ventricular rate control between arms (74% vs. 74%). The median time to ventricular rate control was also similar between arms (6 vs. 7 hours, respectively). In summary, based on these three studies, amiodarone controlled ventricular rate better than digoxin, but the inconsistency across studies and the imprecision of these findings reduced the strength of evidence (low strength of evidence).

#### Calcium Channel Blockers Plus Digoxin Versus Digoxin Alone

The calcium channel blocker diltiazem in combination with digoxin was compared with digoxin alone in patients with AF and rapid ventricular response in one study.151 Successful rate control was defined as ventricular rate <100 bpm persisting for at least 1 hour or conversion to sinus rhythm. All patients achieved successful rate control at 12 hours. The ventricular rates were comparable in both treatment arms throughout the study period (insufficient strength of evidence). The time taken to achieve successful rate control was shorter in patients receiving diltiazem plus digoxin than in patients receiving digoxin alone although was not statistically significant (p=NS). The loss of rate control in the combination treatment arm was significantly less than in the diltiazem alone arm (14 episodes vs. 39; p=0.05). Among patients with episodes of loss of rate control, the combination treatment caused less loss of rate control when compared with digoxin alone (2 episodes vs. 3.5; p=0.04). The only adverse event observed was an episode of sinus pause for 2.5 seconds in one patient who received the combination treatment.

#### Calcium Channel Blockers Versus Digoxin

Four studies compared calcium channel blockers with digoxin.143,145,147,148 In one,145 verapamil was compared with digoxin in patients undergoing elective cardioversion. At 2 weeks after inclusion, the mean heart rate was comparable between patients receiving verapamil and digoxin (82 vs. 82 bpm). In order to obtain adequate rate control, more patients in the digoxin arm were treated with additional beta blocker therapy than in the verapamil arm (60% vs. 38%; p=0.01). In the second study,143 sustained ventricular rate (<90 bpm) within 24 hours was compared between patients receiving digoxin or diltiazem. Patients receiving diltiazem were more likely to achieve sustained heart rate control (90%) than patients receiving digoxin (74%; p=0.047). The median time to ventricular rate control was also significantly shorter in patients receiving diltiazem (3 hours) than in patients receiving digoxin (6 hours; p<0.0001). Patients receiving diltiazem had lower mean ventricular rate after the first hour of drug administration compared with patients receiving digoxin (p<0.05). In a third study,147 patients were more like to have a ventricular rate >90 bpm at 4 weeks when receiving digoxin (15 patients) than when receiving verapamil (5 patients; p<0.05). Importantly, five patients in the verapamil group required concomitant use of digoxin to reach ventricular rate control. Finally, in the last study,148 digoxin was compared with the calcium channel blocker verapamil in patients with new onset AF with rapid ventricular response. The mean reduction in heart rate over 6 hours was 52.1 bpm in the digoxin arm and 41.8 bpm in the verapamil arm (p=0.55). At 6 hours, there was no difference in the rates of sinus rhythm between the two groups (p=0.962; insufficient strength of evidence). Conversion to sinus rhythm tended to be achieved more quickly in the digoxin group than in the verapamil group, although this difference was not statistically significant. Among patients remaining in AF, the reduction in heart rate was greater in patients receiving digoxin (mean reduction 47 bpm) than in patients receiving verapamil (mean reduction 21.6 bpm; p=0.035). Patients receiving verapamil had a greater reduction in heart rate compared with patients receiving digoxin at 0.5 hours (p=0.007) and 1 hour (p=0.027), but no differences were seen between groups at 2, 3, or 4 hours. There were no clear adverse events related to the treatments in this study. Some of the symptoms that were reported, such as lightheadedness and palpitations, seem to have been related to AF and not to the study treatments.

In summary, there was a consistent benefit of verapamil or diltiazem compared with digoxin across studies (high strength of evidence).

#### Results in Specific Subgroups of Interest

One study compared combined treatment with the beta blocker carvedilol plus digoxin with carvedilol alone and with digoxin alone in patients with AF and heart failure in one study.141 The combination of digoxin plus carvedilol was superior to digoxin alone for rate control at 4 months. At 6 months, there was no difference in rate control between digoxin alone and carvedilol alone. The improvement of AF symptoms was greater in patients receiving combined treatment than in patients receiving digoxin alone.). The included studies did not allow a direct comparison of these findings with those in other populations. Other subgroups of interest were not specifically evaluated.

### Strength of Evidence

Our review of rate-control drugs explored the comparative effectiveness of beta blockers, calcium channel blockers, digoxin, and other antiarrhythmics in controlling ventricular rate. The 14 included studies varied in terms of the drugs involved, and the lack of multiple studies exploring similar comparisons decreased our ability to quantitatively synthesize their findings. Our findings highlight the lack of definitive data on the superiority of one beta blocker over another or against calcium channel blockers. Our findings underscore the importance of conducting studies comparing the effectiveness, tolerability and safety of different beta blockers and calcium channel blockers and in different patient populations. Based on a limited number of comparative studies, our analysis suggests that either a calcium channel blocker (verapamil or diltiazem) or amiodarone is beneficial compared with digoxin for rate control. Evidence exploring adverse events and safety and effectiveness of the available agents in specific subgroups of interest was insufficient. Table 4 summarizes the strength of evidence for the studied rate-control drugs and outcomes of interest. In general, the limited number of studies exploring specific comparisons, along with the various metrics used to assess outcomes of interest, reduced our confidence in the findings.

Table 4 Strength of evidence domains for rate-control drugs

Outcome | Number of Studies (Subjects) | Domains Pertaining to SOE | | | | SOE and Magnitude of Effect (95% CI)
Outcome | Number of Studies (Subjects) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect (95% CI)
Beta Blockers vs. Digoxin
Ventricular Rate Control | 1 (47) | RCT/Moderate | NA | Direct | Imprecise | SOE=Insufficient
Beta Blockers vs. Calcium Channel Blockers
Ventricular Rate Control | 1 (40) | RCT/Moderate | NA | Direct | Imprecise | SOE=Insufficient
Beta Blockers vs. Calcium Channel Blockers in Patients Taking Digoxin
Ventricular Rate Control | 1 (29) | RCT/Moderate | NA | Direct | Imprecise | SOE=Insufficient
Exercise Capacity | 1 (29) | RCT/Moderate | NA | Direct | Imprecise | SOE=Insufficient
Quality of Life | 1 (29) | RCT/Moderate | NA | Direct | Imprecise | SOE=Insufficient
Sotalol vs. Metoprolol in Patients Taking Digoxin
Ventricular Rate Control | 1 (23) | RCT/Moderate | NA | Direct | Imprecise | SOE=Insufficient
Amiodarone vs. Calcium Channel Blockers
Ventricular Rate Control | 3 (271) | RCT/Low | Inconsistent | Direct | Imprecise | SOE=Low Amiodarone is comparable to the calcium channel blocker diltiazem for rate control
Amiodarone vs. Digoxin
Ventricular Rate Control | 3 (390) | RCT/Low | Inconsistent | Direct | Imprecise | SOE=Low Amiodarone controlled ventricular rate better than digoxin across 2 studies (both p=0.02) but did not demonstrate a difference in a third study
Calcium Channel Blockers Plus Digoxin vs. Digoxin Alone
Ventricular Rate Control | 1 (52) | RCT/Moderate | NA | Direct | Imprecise | SOE=Insufficient
Calcium Channel Blockers vs. Digoxin
Ventricular Rate Control | 4 (422) | RCT/Low | Consistent | Direct | Precise | SOE=High Consistent benefit of verapamil or diltiazem compared with digoxin (p<0.05 across studies)

Abbreviations: CI=confidence interval; NA=not applicable; RCT=randomized controlled trial; SOE=strength of evidence

## Key Question 2 Strict Versus Lenient Rate-Control Strategies

KQ 2: What are the comparative safety and effectiveness of a strict rate-control strategy versus a more lenient rate-control strategy in patients with atrial fibrillation? Do the comparative safety and effectiveness of these therapies differ among specific patient subgroups of interest?

### Key Points

- Based on one RCT and one observational study (both good quality) involving 828 patients, there was low strength of evidence to support a decrease in strokes for patients on lenient rate control. This decrease was statistically significant in the RCT, but not in the observational study.
- There was insufficient strength of evidence to support comparisons between strict and lenient rate control for other outcomes, specifically for all-cause and cardiovascular mortality, cardiovascular hospitalizations, heart failure symptoms, control of AF symptoms, quality of life, and composite measures.

### Description of Included Studies

Three studies—one RCT17 and two observational studies152,153 representing secondary analyses of RCTs—were included in our analyses. We also included data from a separately published subgroup analysis154 of the one RCT directly included in our analysis17 (Appendix Table F-2). All studies included outpatients from multiple centers, and all were performed in Europe. Of the included studies, two were of good quality17,152 and one was of fair quality.153 All reported multiple funding sources; these included industry,17,152,153 government,153 and nonindustry/nongovernment sources.17,152,153 Studies enrolled patients between 1998 and 2007. The number of patients included in studies ranged from 214^152^ to 1,091,^153^ with some overlap in patient populations across studies; a total of approximately 1,705 unique patients were included, with 1,177 deemed “strict” and 528 deemed “lenient.” The mean age of study participants ranged from 68–69 years. The proportion of male patients included ranged from 59–66 percent. None of the studies reported data on race or ethnicity of subjects. Study durations ranged from 2.3 years152 to 3 years.17,154

Study populations were composed entirely of patients with persistent153 or permanent17,152 AF. Included studies used varying definitions of “strict” and “lenient” rate control. The single included RCT17 used a resting heart rate <80 bpm as the definition of strict rate control and resting heart rate <110 bpm as the definition of lenient rate control, and this definition was accordingly also used by the secondary analysis of this study that examined quality of life.154 One observational study153 compared patients from the rate-control arms of two prior RCTs; one of these RCTs155 used a resting rate-control goal of <80 bpm, and the other156 used a resting rate-control goal of <100 bpm; for the purposes of the observational study included here, the cohort with the resting rate-control goal of <80 bpm was deemed “strict” and the cohort with the resting rate-control goal of <100 bpm was deemed “lenient.”153 A second observational study152 examined data from the rate-control arm of a prior RCT156 and established post hoc definitions of strict (<80 bpm) and lenient (>80 bpm) rate control.

The protocols for the studies included in this analysis all utilized beta blockers, non-dihydropyridine calcium channel blockers, and digoxin, either alone or in combination, to achieve strict and lenient rate-control goals. Detailed information on agents used was provided in all but one of the studies.153 Patients in all studies also received antithrombotic therapy (vitamin K antagonists or aspirin, primarily the former) appropriate to their level of thromboembolic risk as determined by the presence of known thromboembolic risk factors.

### Detailed Synthesis

#### Overview

This analysis addressed the comparative effectiveness of strict versus lenient rate control on a variety of relevant outcomes in patients with AF. Because the included studies used different definitions of strict and lenient rate control, no available data were deemed appropriate for meta-analysis.

#### Ventricular Rate Achieved

As noted above, the included studies each had distinct definitions of strict and lenient rate control. Accordingly, strict and lenient rate-control patients achieved different mean heart rates in different studies. The levels of rate control achieved in each group are presented in Table 5. The “lenient” group from one observational study that compared patients from the rate-control arms of two prior RCTs153 appeared to have tighter heart rate control than the other two relevant studies.153 These differences should be taken into account when interpreting study outcomes.

Table 5 Ventricular rate achieved

Study | Strict Rate Control (bpm±SD) | Lenient Rate Control (bpm±SD) | P Value for Comparison
Van Gelder, 2010^17^ (RCT) | 76±12 | 93±9 | <0.001
Groenveld, 2009^152^ | 76.1 | 83.4 | <0.0001
Van Gelder, 2006^153^ | 72±5 | 90±8 | <0.001

Abbreviation: bpm=beats per minute; RCT=randomized controlled trial; SD=standard deviation

#### All-Cause and Cardiovascular Mortality

The RCT17 and one observational study153 examined incidence of all-cause mortality among patients receiving strict and lenient rate control. Incidence of all-cause mortality ranged from 4–6.6 percent among strict rate-control patients, and from 2–5.6 percent among lenient rate-control patients. The RCT showed a nonsignificant HR of 0.91 (90% CI, 0.52 to 1.59).17 No statistically significant difference in the incidence of all-cause mortality between strict and lenient rate control was observed in either study (insufficient strength of evidence).

The RCT17 and a different observational study152 examined incidence of cardiovascular mortality among patients receiving strict and lenient rate control. Incidence of cardiovascular mortality ranged from 3.9–7 percent among strict rate-control patients, and from 2.9–7 percent among lenient rate-control patients. The RCT showed a HR of 0.79 (90% CI, 0.38 to 1.65), demonstrating a potential benefit of lenient rate control which did not reach statistical significance.17 No statistically significant difference in the incidence of cardiovascular mortality between strict and lenient rate control was observed in either of the included studies (insufficient strength of evidence).

#### Cardiovascular Hospitalizations

The RCT17 and one observational study153 provided details on hospitalizations among patients receiving strict and lenient rate control. With respect to cardiovascular hospitalizations (expressed as a percentage reflecting the number of patients with a hospitalization divided by the total N), numbers ranged from 5.6–28 percent among strict rate-control patients, and from 7.7–22 percent among lenient rate-control patients. Another observational study indicated that “hospitalization for heart failure, thromboembolic complications, and bleeding occurred in similar proportions in both groups,” but did not provide detailed data.152 Ultimately, no statistically significant differences in the incidence of cardiovascular hospitalization between patients receiving strict and lenient rate control were observed in either study (insufficient strength of evidence).

#### Heart Failure Symptoms

The RCT17 and one observational study152 examined incidence of heart failure symptoms among patients receiving strict and lenient rate control. Incidence of heart failure symptoms ranged from 4.1–5 percent in the strict rate-control groups, and from 2–3.8 percent in the lenient rate-control groups. The RCT showed a nonsignificant HR of 0.97 (90% CI, 0.48 to 1.96).17 No statistically significant difference in the incidence of heart failure symptoms between strict and lenient rate control was observed in either study (insufficient strength of evidence).

#### Quality of Life

A secondary analysis154 of the RCT17 and one other observational study152 provided data on patient quality of life as assessed by the SF-36. No significant differences were observed on any of the eight subscales between patients in the strict and lenient rate-control groups in either study (insufficient strength of evidence).

#### Thromboembolic Events

The RCT17 and one observational study152 examined incidence of thromboembolic events (stroke and systemic embolism) among patients receiving strict and lenient rate control. Incidence of thromboembolic events ranged from 3.9–7 percent among strict rate-control patients, and from 1.6–5 percent among lenient rate-control patients. Although favoring lenient control, no statistically significant difference in rate of thromboembolic events was seen in the observational study (absolute difference of 1.6; 95% CI, -5.3 to 8.6).152 For the RCT, significance data were presented separately for stroke and systemic embolism; a statistically significant difference in stroke rate was observed, with a HR of 0.35 (90% CI, 0.13 to 0.92) in the direction of lenient rate control, with 0.3 percent of patients in the lenient rate-control group suffering a systemic embolism compared with no patients in the strict rate-control group.17 However, although it was a good quality study, this RCT used a prespecified 90 percent CI, and it is not clear whether this conclusion of noninferiority for stroke would be equally valid using a statistical significance of p<0.05 (low strength of evidence).

#### Bleeding Events

The RCT17 and one observational study152 examined incidence of bleeding events among patients receiving strict and lenient rate control. Incidence of bleeding events ranged from 4.5–7 percent among strict rate-control patients, and from 4–5.3 percent among lenient rate-control patients. The RCT showed a nonsignificant HR of 1.12 (90% CI, 0.60 to 2.08).17 No statistically significant difference in the incidence of bleeding events between strict and lenient rate control was observed in either study (insufficient strength of evidence).

#### Composite Outcomes

The included studies examined a variety of composite outcomes as primary outcomes. As described in the articles, these included: (1) death from cardiovascular causes, hospitalization for heart failure, stroke, systemic embolism, major bleeding, arrhythmic events (including syncope), sustained ventricular tachycardia, cardiac arrest, life-threatening adverse effects of rate-control drugs, and implantation of a pacemaker or cardioverter-defibrillator;17 (2) all-cause death, cardiovascular hospitalization, and myocardial infarction;153 and (3) cardiovascular death, heart failure, thromboembolic complications, bleeding, severe adverse effects of antiarrhythmic drugs, and pacemaker implantations.152

Composite outcome incidence ranged from 14.9–34 percent among strict rate-control patients, and from 12.9–25 percent among lenient rate-control patients. The single available RCT showed a nonsignificant hazard ratio (HR) of 0.84 (90% CI, 0.58 to 1.21) for a reduction in the composite outcome.17 No statistically significant difference in composite primary outcome between strict and lenient rate control was observed in any of the included studies, despite the use of distinct composite outcomes and unique definitions for strict and lenient rate control.

#### Other Outcomes

Other outcomes were reported infrequently. The RCT reported that 46.0 percent of the strict-control group and 45.6 percent of the lenient rate-control group had experienced symptoms associated with AF by the end of the study (p=0.92), including dyspnea, fatigue, and palpitations.17 Additionally, 1.4 percent of strict rate-control patients and 0.8 percent of lenient rate-control patients required pacemaker implantation for refractory AF symptoms (p=NS). Two observational studies also reported data on pacemaker implantation for patients with refractory rate control; one reported an incidence of pacemaker implantation of 11 percent in the strict rate-control group and 1 percent in the lenient rate-control group (p=0.0001),153 while the other reported an incidence of 0 percent in the strict rate-control group and 2 percent in the lenient rate-control group (p=NS).152 One observational study reported data on myocardial infarction, with an incidence of 2 percent in the strict rate-control group and 1 percent in the lenient rate-control group (p=NS).153

#### Adverse Events

Reporting of adverse events attributable to rate-controlling drugs was inconsistent across studies. The RCT reported an adverse event rate of 23.8 percent among patients receiving strict rate control and 19.9 percent among patients receiving lenient rate control (p=0.2; reported events included dizziness, fatigue, and dyspnea), with 0.7 percent of the strict rate-control group and 1.1 percent of the lenient rate-control group experiencing a “life-threatening adverse effect of rate-control drugs.”17 One observational study reported a single severe adverse event attributable to rate-control drugs in each group (atrioventricular nodal escape rhythm due to digoxin intoxication in the strict rate-control group, and symptomatic bradycardia with atrioventricular nodal escape rhythm during beta blocker therapy in combination with digoxin in the lenient rate-control group),152 but otherwise no other study reported adverse events (insufficient strength of evidence).

#### Results in Specific Subgroups of Interest

No results were reported for outcomes of interest in specific subgroups of interest.

### Strength of Evidence

Our review identified only one RCT and two observational studies representing secondary analyses of RCTs exploring the comparative safety and effectiveness of strict versus lenient rate-control strategies. In general, these studies were consistent in showing no significant difference between strict and lenient rate control with respect to mortality, cardiovascular hospitalizations, heart failure symptoms, quality of life, thromboembolic events, bleeding events, and composite outcomes. However, the RCT differed from the observational studies in showing a statistically significantly lower stroke rate with lenient rate control. By emphasizing the limitations in the available data and the paucity of data on lenient versus strict rate control, our findings highlight the need for more research in this area. Table 6 summarizes the strength of evidence for the outcomes of interest and illustrates how the current evidence base is insufficient to provide conclusive estimates of the effect of strict and lenient rate-control strategies. Note that because the one RCT was powered as a noninferiority trial the risk of bias was estimated to be moderate rather than low.

Table 6 Strength of evidence domains for strict versus lenient rate-control strategies

Outcome | Number of Studies (Subjects) | Domains Pertaining to SOE | | | | SOE and Magnitude of Effect (95% CI)
Outcome | Number of Studies (Subjects) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect (95% CI)
All-Cause Mortality | 1 (614) | RCT/Moderate | NA | Direct | Imprecise | SOE=Insufficient
CV Mortality | 2 (828) | RCT/Moderate Observational/Moderate | Consistent | Direct | Imprecise | SOE=Insufficient
CV Hospitalizations | 2 (1,705) | RCT/Moderate Observational/Moderate | Consistent | Direct | Imprecise | SOE=Insufficient
Heart Failure Symptoms | 2 (828) | RCT/Moderate Observational/Moderate | Consistent | Direct | Imprecise | SOE=Insufficient
Quality of Life | 2 (828) | RCT/Moderate Observational/Moderate | Consistent | Direct | Imprecise | SOE=Insufficient
Thromboembolic Events | 2 (828) | RCT/Moderate Observational/Moderate | Consistent | Direct | Precise | SOE=Low HR 0.35 (90% CI, 0.13 to 0.92) in RCT favoring lenient control; while also favoring lenient control, the observational study did not demonstrate a statistically significant difference (absolute difference of 1.6; 95% CI -5.3 to 8.6)
Bleeding Events | 2 (828) | RCT/Moderate Observational/Moderate | Consistent | Direct | Imprecise | SOE=Insufficient

Abbreviations: CI=confidence interval; CV = cardiovascular; HR=hazard ratio; NA=not applicable; RCT=randomized controlled trial; SOE=strength of evidence

## Key Question 3 Rate-Control Procedures Versus Drugs or Versus Other Procedures in Patients for Whom Initial Pharmacotherapy Was Ineffective

KQ 3: What are the comparative safety and effectiveness of newer procedural and other nonpharmacological rate-control therapies compared with pharmacological agents in patients with atrial fibrillation for whom initial pharmacotherapy was ineffective? Do the comparative safety and effectiveness of these therapies differ among specific patient subgroups of interest?

### Key Points

Procedures versus drugs
- Based on 3 studies (1 good, 2 poor quality) involving 175 patients, patients undergoing a procedural intervention had a significantly lower heart rate at 12 months than those receiving a primarily pharmacological intervention (moderate strength of evidence).
- There was no difference by treatment arm in all-cause mortality (2 studies [1 good, 1 fair quality], 201 patients); cardiovascular mortality (1 study [good quality], 102 patients); or exercise capacity (2 studies [1 good, 1 fair quality], 135 patients) (all low strength of evidence).
- There was insufficient strength of evidence to support findings for other outcomes, including quality of life.

One procedure versus another
- Based on 1 study (fair quality) involving 40 patients, there was no difference in ventricular rate control between those assigned to an anterior versus posterior ablation approach (low strength of evidence).
- Based on 1 study (fair quality) involving 184 patients, there was no significant difference in all-cause mortality between those receiving biventricular pacing versus those receiving right ventricular (RV) pacing (low strength of evidence).
- Based on 1 study (fair quality) involving 184 patients, there were significant improvements in exercise capacity for those in the biventricular pacing group compared with those receiving RV pacing (low strength of evidence).
- There was insufficient strength of evidence to support findings of other outcomes, including quality of life.

### Description of Included Studies

Six RCTs (2 good, 3 fair, and 1 poor quality) involving a total of 537 patients met the inclusion criteria for KQ 3 (Appendix Table F-3), evaluating the comparative effectiveness of a procedural intervention versus a primarily pharmacological intervention for rate control of AF,157-160 or comparing two primarily procedural interventions.161,162 We also included data from a separately published subgroup analysis163 of one of the RCTs.160 One study each was based in the UK,158 continental Europe,159 and Asia;161 one was a multicenter trial based in Australia (Australian Intervention Randomized Control of Rate in Atrial Fibrillation Trial [AIRCRAFT]);160 one was a multicenter trial in the United States and Canada;162 and one did not specify the geographical location.157 All studies were unblinded due to the nature of the interventions, although one was described to be patient-blinded.162 Four studies recruited patients with only one specific type of AF, either permanent158,160,162 or persistent;159 one study recruited patients with “resistant chronic” AF;157 and one study recruited patients with permanent or paroxysmal AF.161 These studies, however, evaluated and compared different types of treatments, preventing conclusions about whether effectiveness varied by type of AF. Treatment arms ranged in size from 18–103 patients. Three studies reported outcomes at 6 months.158,160,162 Three studies reported outcomes at 12 months;157,158,160 for one of these,160 outcomes were also reported for a subgroup of the original study population at approximately 5 years.163 One study159 reported outcomes with a mean followup period of approximately 26 months. Finally, one study reported outcomes at an unclear time point, which is presumed to be immediately after the procedure was completed, as well as at 14 months.161 Three studies reported their funding source, which was from industry for two studies,160,162 and at least partially from a governmental organization in the other.161

In line with our a priori definition of rate-control procedures, all studies included at least one treatment arm with radiofrequency ablation of either the atrioventricular node (AVN) or His bundle, most often in conjunction with pacemaker placement. The comparison arms included a pharmacological intervention whose main purpose was to control ventricular heart rate rather than converting the underlying rhythm of AF, based on the description of outcomes; this was combined with a procedure in some studies. One study compared AVN ablation plus pacing of the His bundle area versus treatment with amiodarone at a dose of 200–400 mg a day.157 Another study compared AVN ablation plus ventricular demand rate-responsive (VVIR) pacing versus a pharmacological intervention for ventricular rate control, including digoxin, beta blockers, and calcium channel blockers, alone or in combination, as selected by the treating health care provider.160 In one study, all patients had placement of a VVIR-programmed pacemaker, followed by randomization to either a His bundle ablation or pharmacological treatment to assist with ventricular heart rate control, with medications including calcium channel blockers, digoxin, or beta blockers.158

In two studies, all patients had AVN ablation, but were randomized to different types of pacing strategies. In one of these studies, all patients underwent AVN ablation for chronic AF and were randomized to chronic biventricular pacing versus right ventricular (RV) pacing.162 In the other study, in addition to AVN ablation, participants were randomized to dual chamber demand rate-responsive (DDDR) pacing in conjunction with antiarrhythmic therapy with medicines such as propafenone, sotalol, or amiodarone, versus VVIR pacing with no additional antiarrhythmic therapy.159 Finally, one study compared anterior and posterior approaches to AVN ablation for rate control.161

### Detailed Synthesis

#### Ventricular Rate Control

Four studies reported outcomes related to ventricular rate control based on 24-hour Holter monitor,157,158,160,161 but only three of these presented actual measures of heart rates achieved with the different treatments (Table 7).158,160,161 Three studies compared a primarily procedural intervention with a primarily pharmacological intervention;157,158,160 one compared two primarily procedural interventions with one another.161

Table 7 Heart rate results (24-hour Holter monitor)

Study | Sample Size (N) | Timing of Outcome | Interventions | Minimum Heart Rate^a^ | Mean Heart Rate^a^ | Maximum Heart Rate^a^
Procedures vs. drugs
Levy, 2001^158^ | 36 | 1 month | VVIR pacing + His bundle ablation | 60 (programmed) | 71±6^b^ | 113±17
Levy, 2001^158^ | 36 | 1 month | VVIR pacing + rate-control medications | 70 (programmed) | 83±8 | 116±19
Weerasooriya, 2003^160^ | 99 | 1 month | VVIR pacing+ AVN ablation | 80±12^c^ | 87±9^c^ | 117±14^c^
Weerasooriya, 2003^160^ | 99 | 1 month | Rate-controlling medications | 44±14 | 76±12 | 147±44
Weerasooriya, 2003^160^ | 99 | 12 months | VVIR pacing + AVN ablation | 70±9^c^ | 76±7^c^ | 117±16^c^
Weerasooriya, 2003^160^ | 99 | 12 months | Rate-control medications | 39±9 | 71±11 | 152±37
Lim, 2007^163^ | 99 | 4-6 years (subgroup) | VVIR pacing + AVN ablation | 60±9^c^ | 79±6 | 108±12^c^
Lim, 2007^163^ | 99 | 4-6 years (subgroup) | Rate-control medications | 44±13 | 72 ±11 | 132±29
One procedure vs. another
Lee, 2000^161^ | 40 | 14 months | Anterior approach for AVN ablation | 63±10 | 82±11 | 128±14
Lee, 2000^161^ | 40 | 14 months | Posterior approach for AVN ablation | 66±11 | 86±10 | 131±16

a Results given in beats per minute (bpm), mean ± standard deviation (SD).

b p<0.01 versus comparator.

c p<0.05 versus comparator.

Abbreviations: AVN=atrioventricular node; VVIR=ventricular demand rate-responsive

##### Procedures Versus Drugs

Three studies found that patients in the primarily procedural intervention arm had a significantly lower heart rate at 12 months than those receiving the primarily pharmacological intervention (moderate strength of evidence). The studies used different measures based on 24-hour Holter monitor—either maximal heart rate or mean heart rate. One study comparing AVN ablation plus pacing of the His bundle area versus amiodarone found that after 3 weeks of treatment, 100 percent of the patients who had undergone AVN ablation with pacemaker achieved a normal ventricular rate, defined as 50–90 bpm, compared with only 57.9 percent of those receiving amiodarone.157 Also, none of the patients who received AVN ablation with pacemaker had an uncontrolled heart rate, defined as >90 bpm at rest or >130 bpm on exertion, while 42.1 percent of patients receiving amiodarone did have uncontrolled heart rate by these parameters (p<0.001). In this same study, 100 percent of patients who had undergone AVN ablation with pacemaker achieved a normal ventricular rate at 12 months, compared with only 33.6 percent of those receiving amiodarone. Also, none of the patients who received AVN ablation with pacemaker had an uncontrolled heart rate at 12 months, while 66.4 percent of patients receiving amiodarone did have uncontrolled heart rate (no statistical results given).

In the study comparing VVIR pacing plus His bundle ablation versus VVIR pacing plus rate-control medications, at 1-month followup, those receiving the ablation had a lower mean heart rate over 24 hours, based on 24-hour Holter recordings, with a mean heart rate of 71±6 bpm compared with 83±8 bpm in the medication arm (p<0.01).158 Mean heart rates were described as being similar to these values through 1 year of followup. Resting heart rates also differed between groups, but this difference was thought to be due to the fact that the lower heart rate was programmed on the pacemakers differently in the two groups, with the ablation group having the lower heart rate set at 60 bpm and the medication group having the lower heart rate set at 70 bpm. The maximum heart rate, as measured on the 24-hour Holter recordings, did not differ significantly between the two groups.

In another study, at 12 months, based on 24-hour ambulatory electrocardiograms (ECGs), those receiving AVN ablation plus VVIR pacing compared with those on medication alone had significantly higher minimum heart rates (70±9 vs. 39±9 bpm; p<0.05) and mean heart rates (76±7 vs. 71±11 bpm; p<0.05).160 However, those receiving the ablation had significantly lower maximum heart rates compared with those on medication alone on 24-hour tapes (117±16 vs. 152±37 bpm; p<0.05).

For the last study described above,160 longer term outcomes were reported separately163 for a subgroup of the original study population comprising 48 participants from two of the study sites, representing about 48 percent of the original study population. For this subgroup, investigators reported that at approximately 5 years of followup, minimum heart rate (assessed by 24-hour Holter monitor) was still higher in those receiving AVN ablation plus VVIR pacing than in those receiving medication alone (60±9 bpm vs. 44±13; p<0.05). Mean heart rates were not significantly different, but maximum heart rate was again lower in those receiving ablation plus VVIR pacing than in those receiving medication alone (108±12 vs. 132±29 bpm; p<0.05).

##### One Procedure Versus Another

The study that compared two different approaches for performing AVN ablation—an anterior approach and a posterior approach—defined immediate success of the procedure with reference to heart rate parameters including a heart rate of approximately 120–130 bpm during infusion of isoproterenol (4 mcg/min) or an average ventricular rate of approximately 70–75 percent of the baseline ventricular rate during infusion of isoproterenol (4 mcg/min).161 Seventy-eight percent of patients receiving the anterior approach achieved this result, compared with 64 percent receiving a posterior approach (statistical test not reported). Allowing for crossovers for those who did not achieve the outcome described above, results of 24-hour Holter monitors were compared at approximately 14 months of followup. These results found no statistically significant difference between those assigned to the anterior versus posterior approaches based on minimal, mean, or maximal heart rates (low strength of evidence).

#### Mortality, Cardiovascular Events, and Cardiovascular Hospitalizations

##### Procedures Versus Drugs

Two studies analyzed long-term clinical outcomes in patients with persistent or chronic AF,159,160 one of which160 reported long-term mortality separately for a subgroup of its population.163 The primary outcome of the first study,159 which compared AVN ablation plus DDDR pacing and antiarrhythmic therapy versus AVN ablation plus VVIR pacing alone, was the occurrence of stroke or cardiovascular mortality. Secondary outcomes included all-cause mortality, development of permanent AF, cardiovascular hospitalizations, heart failure, and myocardial ischemia. Mean followup time for both treatment arms was similar at 26 months. This study found that there was no statistically significant difference in the primary outcome between the treatment arms, with an event rate of 5.3 percent per year in patients with the VVIR pacing compared with 5.9 percent in patients with the DDDR pacing and medications (p=0.930). There was also no statistically significant difference in all-cause mortality, with event rates of 4.3 and 4.8 percent for those with the VVIR and DDDR pacing, respectively (OR 0.98; 95% CI, 0.25 to 3.53; p=0.74). Fewer patients receiving DDDR pacing plus medication developed permanent AF compared with patients receiving VVIR pacing (OR 0.06; 95% CI, 0.02 to 0.17; p<0.001). However, those patients receiving VVIR pacing had fewer cardiovascular hospitalizations compared with those receiving the DDDR pacemaker and medications, with 9 versus 31 hospitalizations, respectively (p<0.001). There was no statistically significant different in the occurrence of heart failure or myocardial ischemia between the two treatment groups.

In the study comparing AVN ablation plus VVIR pacing versus rate-control medication, there was no significant difference in all-cause mortality or cardiovascular events at 12 months. There were two deaths in the ablation arm and one death in the medication arm (p=0.617); two acute myocardial infarctions (MIs) in the ablation arm and one in the medication arm (p=0.617); and four cases of unstable angina in the ablation arm and one in the medication arm (p=0.204). Hospitalizations were not reported.160 At a mean of 5.4±0.9 years of followup, in the subgroup of 48 patients that were reevaluated for clinical outcomes, there were 15 total deaths, with no statistically significant difference in survival between treatment groups (p=0.26).163

We rated the findings of no significant difference for all-cause and cardiovascular mortality as having a low strength of evidence.

##### One Procedure Versus Another

In a study comparing AVN ablation plus biventricular pacing versus AVN ablation plus RV pacing, total mortality was reported over a 3-year period. This study found no statistically significant difference in mortality for these two treatment groups, with 8 and 18 percent deaths (p=0.16), respectively, for those with biventricular pacing and RV pacing (low strength of evidence).162

#### Exercise Capacity

##### Procedures Versus Drugs

Two studies evaluated exercise capacity at 12 months using treadmill tests,158,160 and neither showed statistically significant differences by treatment arm (low strength of evidence). In the study comparing VVIR pacing plus His bundle ablation versus VVIR pacing plus rate-control medications,158 exercise capacity was tested using a symptom-limited treadmill exercise test. In this study, both groups had a significant improvement in exercise duration of approximately 20 and 40 percent, respectively, but the improvements were not statistically significantly different between treatment groups (full statistical results not reported in paper). In the study comparing AVN ablation plus VVIR pacing versus rate-control medication,160 all patients also underwent treadmill exercise tests. At 12 months, neither group had any significant improvement in exercise duration, and exercise duration at baseline and at 12 months did not differ significantly between groups. The maximum heart rate achieved with exercise was significantly lower, however, in patients receiving ablation compared with those receiving medication (112±17 vs. 153±36 bpm; p<0.05).

##### One Procedure Versus Another

One study compared AVN ablation plus biventricular pacing versus AVN ablation plus RV pacing and evaluated exercise capacity based on 6-minute walk test distance.162 This study found improvement in both arms from preablation measures to 6 months postprocedure. However, the improvement in walking distance was significantly greater among those in the biventricular pacing group at 82.9±94.7 m compared with 61.2±90.0 m for those receiving RV pacing (p=0.04) (low strength of evidence).162

#### Quality of Life

##### Procedures Versus Drugs

Two studies described outcomes related to quality of life at 6 or 12 months, but they used different measurement tools and differed in their results.158,160 In the study comparing VVIR pacing plus His bundle ablation versus VVIR pacing plus rate-control medications,158 the burden of cardiac symptoms was measured using a modified Karolinska Questionnaire, which has been validated for patients with pacemakers.164 This study also administered the Nottingham Health Profile to measure general quality of life, a tool previously validated in cardiac patients.165,166 Patients in both treatment arms had significant improvements over the 12-month followup period both in their burden of cardiac symptoms and in their general quality of life; however, there was no statistically significant difference in these improvements by treatment arm (full statistical results not provided in the paper for either measure).

In the study comparing AVN ablation plus VVIR pacing versus rate-control medications,160 three health-related quality-of-life questionnaires were administered: the Australian Quality of Life Questionnaire (AQoL), a generic utility instrument validated for use in a wide range of illnesses and interventions;167 the quality-of-life questionnaire used in the Cardiac Arrhythmia Suppression Trial (CAST), validated in patients with heart disease;168 and the Sickness Impact Profile (SIP), validated for use in patients with a wide-range of illnesses and disease severities.169 Based on two of these three measures, there was no statistically significant difference in the change in quality of life, which was minimal, between treatment groups at 12 months. However, based on the CAST measure, those patients who received AVN ablation plus VVIR pacing had significantly improved ratings of their quality of life compared with those on medications, with a relative risk reduction in symptoms of 18 percent (p=0.004).160

Long-term followup on quality-of-life measures was reported separately163 for a subgroup of participants in the second trial described above.160 There were no statistically significant differences between groups at 5 years in the AQoL measures (no p-value given) or in SIP scores (p=0.16). Overall life satisfaction scores and psychosocial scores on the CAST questionnaire also did not differ between treatment groups (p>0.05); however, those patients who received AVN ablation plus VVIR pacing did have a reduction in certain symptoms evaluated by the CAST questionnaire compared with those on medication alone, with a reduction in symptoms of irregular heart beat (p<0.001), chest pain (p=0.02), and difficulty breathing (p=0.02).

The strength of evidence was rated as insufficient to determine the impact of the interventions on quality of life.

##### One Procedure Versus Another

In the study comparing AVN ablation plus biventricular pacing versus AVN ablation plus RV pacing,162 there was reportedly no difference in quality of life at 6 months between treatment arms as measured by the SF-36 Health Status Scale (detailed results were not provided; insufficient strength of evidence).

#### Adverse Events

##### Procedures Versus Drugs

Three studies described adverse events, with one study160 including a second publication describing long-term outcomes of the interventions.163 In the two studies using antiarrhythmic drugs,157,159 two patients reported adverse events, including one episode of torsade-de-points in a patient receiving sotalol and one case of heart failure in a patient receiving propafenone.159 No adverse reactions were reported by patients receiving amiodarone.157 One study using rate-control drugs reported adverse events,160 finding three hematomas in the ablation arm, as well as one pulmonary embolus. During long-term followup of this study, two patients who received ablation plus pacing developed heart failure, one patient who received ablation plus pacing developed failure to capture related to malfunction of their pacemaker, and one patient in the medication arm experienced prolonged pauses with their AF and required pacemaker placement.163

##### One Procedure Versus Another

In the study comparing AVN ablation plus biventricular pacing versus AVN ablation plus RV pacing, overall numbers of complications were reported for a 3-year period and included adverse events related to pacemaker dysfunction, such as diaphragmatic stimulation, lead dislodgement, and oversensing, as well as adverse events related to pacemaker placement including pneumothorax, hematoma, and infection.162 There was no significant difference in overall complication rates between treatment arms, with rates of 15 and 6 percent (p=0.06) for those with biventricular pacing and RV pacing, respectively.

#### Subgroups of Interest

##### Procedures Versus Drugs

One study evaluated outcomes at 1 year according to a prespecified subgroup analysis in 19 patients with left ventricular ejection fraction (LVEF) ≤45 percent who were randomized to either AVN ablation plus VVIR pacing or rate-control medication. This study found that the results of heart rate changes or exercise capacity by treatment group did not differ from the main study for this subgroup.160

##### One Procedure Versus Another

The study comparing AVN ablation plus biventricular pacing versus AVN ablation plus RV pacing also evaluated 6-month outcomes of subgroups of participants based on LVEF. This study found that among participants with an LVEF >45 percent (n=89), both treatment arms had improvements in 6-minute walk distance, and there was no significant difference between treatment groups in this improvement. However, among participants with an LVEF ≤45 percent (n=76), those participants receiving biventricular pacing had significantly greater improvements in their 6-minute walk distance compared with those receiving RV pacing, with improvements of 96.9±97.7 m and 55.9±96.1 m, respectively (p=0.04). This study also compared outcomes for patients with different functional classes of heart failure based on New York Heart Association (NYHA) symptoms. Similar to the pattern observed for patients by LVEF, those with NYHA class I symptoms demonstrated similar improvements in 6-minute walk distance (p=0.29), while those with either NYHA class II or III symptoms had significantly greater improvements in 6-minute walk distance with biventricular pacing compared with RV pacing (p=0.01).162

### Strength of Evidence

Tables 8 and 9 summarize the strength of evidence for the various comparisons and outcomes of interest. Studies varied in the type of procedures and drugs that were tested, limiting our ability to synthesize evidence across studies. Studies that explored the impact of procedures versus drugs on ventricular rate control demonstrated a significantly lower heart rate in patients in the procedural intervention arms. Other outcomes assessed either found no differences by treatment arm (exercise capacity, mortality) or were inconsistent (quality of life). Studies that evaluated one rate-control procedure versus another did not find differences in rate control or all-cause mortality but did demonstrate an improvement in exercise capacity among those in a biventricular pacing group compared with right ventricular pacing. Our findings underscore the need for additional studies to compare rate-control procedures with rate-control drugs or other procedural interventions with in relation to these outcomes. Although based on direct and mostly consistent evidence, the low number of studies, imprecise findings, and inability to determine a summary effect given the variability in study design and population lowered our confidence in the evidence.

Table 8 Strength of evidence domains for rate-control procedures versus drugs

Outcome | Number of Studies (Subjects) | Domains Pertaining to SOE | | | | SOE and Magnitude of Effect (95% CI)
Outcome | Number of Studies (Subjects) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect (95% CI)
Ventricular Rate Control | 3 (175) | RCT/Low | Consistent | Direct | Imprecise | SOE=Moderate Using different metrics, all 3 studies found that patients in the procedure arm had a significantly lower heart rate at 12 months than those on drugs
All-Cause Mortality | 2 (201) | RCT/Low | Consistent | Direct | Imprecise | SOE=Low No significant difference
CV Mortality | 1 (102) | RCT/Low | NA | Direct | Imprecise | SOE=Low No significant difference
Exercise Capacity | 2 (135) | RCT/Low | Consistent | Direct | Imprecise | SOE=Low Studies did not show significant differences between procedure and drug arms
Quality of Life | 2 (135) | RCT/Low | Inconsistent | Direct | Imprecise | SOE=Insufficient

Abbreviations: CI=confidence interval; NA=not applicable; RCT=randomized controlled trial; SOE=strength of evidence

Table 9 Strength of evidence domains for one rate-control procedure versus another

Outcome | Number of Studies (Subjects) | Domains Pertaining to SOE | | | | SOE and Magnitude of Effect (95% CI)
Outcome | Number of Studies (Subjects) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect (95% CI)
Ventricular Rate Control | 1 (40) | RCT/Low | NA | Direct | Imprecise | SOE=Low No difference between those assigned to anterior vs. posterior approach
All-Cause Mortality | 1 (184) | RCT/Low | NA | Direct | Imprecise | SOE=Low No significant difference among those in the biventricular pacing group compared with those receiving RV pacing (p=0.16)
Exercise Capacity | 1 (184) | RCT/Low | NA | Direct | Imprecise | SOE=Low Improvement in walking distance significantly greater among those in the biventricular pacing group compared with those receiving RV pacing (p=0.04)
Quality of Life | 1 (184) | RCT/Low | NA | Direct | Imprecise | SOE=Insufficient

Abbreviations: CI=confidence interval; NA=not applicable; RCT=randomized controlled trial; RV=right ventricular; SOE=strength of evidence

## Key Question 4 Antiarrhythmic Drugs and Electrical Cardioversion for Conversion to Sinus Rhythm

KQ 4: What are the comparative safety and effectiveness of available antiarrhythmic agents and electrical cardioversion for conversion of atrial fibrillation to sinus rhythm? Do the comparative safety and effectiveness of these therapies differ among specific patient subgroups of interest?

### Key Points

- Based on 4 RCTs (2 good, 2 fair quality) involving 411 patients, use of a single biphasic waveform is more effective in restoring sinus rhythm than use of a single monophasic waveform in patients with persistent AF (high strength of evidence).
- Based on 4 RCTs (1 good, 3 fair quality) involving 393 patients, there was no statistically significant difference in restoration of sinus rhythm with use of anterolateral versus anteroposterior positioning of cardioversion electrodes in patients with persistent AF (low strength of evidence).
- Based on 3 studies (1 good, 2 fair quality) involving 432 patients, a 360 Joules (J) monophasic shock restores sinus rhythm more effectively than a 200 J monophasic shock (high strength of evidence).
- Although based on limited studies and use of different drugs for pretreatment, current evidence suggests that drug pretreatment does not enhance electrical cardioversion in terms of restoration of sinus rhythm (2 studies [1 good, 1 fair quality], 218 patients, moderate strength of evidence), but does increase maintenance of sinus rhythm (2 studies [1 good, 1 fair quality], 195 patients, moderate strength of evidence), and decrease recurrence of AF (1 poor-quality study, 88 patients, low strength of evidence).
- Based on 4 studies (2 good, 2 fair quality) involving 736 patients, amiodarone demonstrates a potential benefit compared with sotalol for restoring sinus rhythm, although the difference did not reach statistical significance (low strength of evidence).

### Description of Included Studies

A total of 42 RCTs involving 5,780 patients were identified that assessed the use of antiarrhythmic drugs or electrical cardioversion for the conversion of AF to sinus rhythm (Appendix Table F-4). Thirteen studies were considered to be of good quality,140,170-181 27 of fair quality,144,145,147,149,182-204 and 2 of poor quality.205,206 The studies were published from the years 2000 through 2011; however, all but four studies170,171,188,196 were published in 2007 or earlier. Eleven studies were multicenter,145,147,171,172,179,180,189,190,197,198,206 28 were single-center,140,144,149,170,173-178,182-188,191-196,200-203,205 and in 3 studies the number of sites was unclear or not stated.181,199,204 Only 7 studies included sites in the United States;172,179,180,182,189,197,198 25 included sites in Europe.140,144,145,147,170,175-179,187,188,191-196,200-206 The study population consisted entirely of patients with persistent AF in 25 studies,144,145,147,170-172,175-178,183,185-187,192-195,197-199,202-204,206 entirely of patients with paroxysmal AF in 1 study,189 and entirely of patients for whom prior rate- or rhythm-control therapy had been ineffective in 2 studies.174,195 Funding was unclear or not reported in 31 studies.140,144,147,170,172,173,175,179,181,183,185-188,190-206 Seven studies used industry funding,145,171,174,176,178,180,184 none was government-only funded, and eight were funded by nongovernment/nonindustry sources.145,149,171,174,177,178,182,189 In the majority of studies, the setting was not reported (18 studies145,179,181,183-187,193,195,197-203,206). Of the remaining studies, 7 were inpatient,140,144,174,177,182,191,205 5 were in the emergency room,149,170,173,189,190 10 were outpatient,147,171,172,175,176,178,180,192,194,204 and 2 were in more than one setting.188,196

Figure 5 represents the treatment comparisons evaluated for this KQ.

Figure 5 Overview of treatment comparisons evaluated for KQ 4^a^ a Lines running from one oval back to the same oval (e.g., “Antiarrhythmic Drugs” oval) indicate intraclass comparisons (e.g., comparison of one antiarrhythmic drug with another). Numbers refer to numbers of comparisons.

Abbreviations: KQ=Key Question; J=Joules; Tx=treatment

This figure shows the number of direct comparisons between treatments evaluated in KQ 4. Twenty-one studies compared methods of external electrical cardioversion, four studies compared electrical cardioversion augmented by medications (metoprolol, verapamil, and ibutilide) to electrical cardioversion alone, and eight studies compared the efficacy of drugs used both prior to and after external electrical cardioversion (amiodarone [five studies], diltiazem [two studies], digoxin [five studies], verapamil [three studies] sotalol [three studies]). Nine studies compared drugs without (or prior to) external electrical cardioversion. No study compared electrical cardioversion directly to pharmacologic cardioversion. Of the 42 studies, 3 had a placebo arm, and 2 had a “control” arm that was not included in this review. Excluding the placebo/control arm in these five studies, one study had four intervention arms, and five studies had three intervention arms. The remaining 36 studies had 2 intervention arms each.

Twenty-one studies compared methods of external electrical cardioversion, four studies compared electrical cardioversion augmented by medications (metoprolol,178 verapamil,199,205 and ibutilide195) with electrical cardioversion alone, and eight studies evaluated the efficacy of drugs used both prior to and after external electrical cardioversion (amiodarone [five studies144,149,180,181,204], diltiazem [two studies144,204], digoxin [five studies145,147,149,204,206], verapamil [three studies,145,147,206], sotalol [three studies149,180,181]). Nine studies compared drugs without (or prior to) external electrical cardioversion.140,170,177,188-193 No study compared electrical cardioversion directly with pharmacological cardioversion. Of the 42 studies, 3 had a placebo arm,170,180,193 and 2 had a “control” arm that was not included in this review.181,192 Excluding the placebo/control arm in these five studies, one study had four intervention arms,198 and five studies had three intervention arms each.149,170,172,190,204 The remaining 36 studies had 2 intervention arms each.

The primary outcome reported for this KQ was restoration of sinus of rhythm within a specified time period following the intervention. This time period ranged from immediately following the intervention to 6 weeks following the intervention. Several studies presented outcome data at multiple time points following the intervention, while others assessed time to outcome within a prespecified time frame. Only three studies did not report restoration of sinus rhythm.194,199,205 Of these, one assessed maintenance of sinus rhythm at 1 week following electrical cardioversion or verapamil plus electrical cardioversion,199 another reported maintenance of sinus rhythm 1 month after electrical cardioversion,194 and the third reported recurrence of AF within 1 week following verapamil with electrical cardioversion versus electrical cardioversion alone.205

Three studies reported an outcome relevant to this KQ in addition to restoration of sinus rhythm. One study reported all-cause mortality, mixed embolic events, and maintenance of sinus rhythm at 6 weeks;185 one reported recurrence of AF within 24 hours after cardioversion;191 and one reported recurrence of AF within 1 minute of electrical cardioversion.202

### Detailed Synthesis

#### Comparisons of Various Methods for External Electrical Cardioversion

##### Overview

Twenty-one studies (2,996 patients) compared different methods of external electrical cardioversion. Nine studies (1,219 patients) compared a biphasic waveform with a monophasic waveform (Table 10), and 4 studies (393 patients) compared anterolateral versus anteroposterior positioning of the defibrillation electrodes (paddles in 2 studies, paddles and/or gel pads in 1 study, and pads in 1 study).175,183,187,202 Three studies (432 patients) included a comparison of an initial 200 J shock with an initial 360 J shock.172,185,186 The remaining five studies addressed comparisons in polarity (one study197), shapes of the biphasic waveform (one study182), composition of the cardioversion electrodes (one study176), and different amounts of energy delivered (two studies171,198).

Table 10 Studies evaluating biphasic versus monophasic waveform

Study | Biphasic Protocol | Monophasic Protocol | N | Outcomes Assessed
Ambler, 2006^184^ | 100 J, 200 J, 300 J, 360 J, 360 J | 70 J, 110 J, 150 J, 200 J, 360 J | 128 | – Restoration of SR immediately; – Restoration of SR at 30 minutes
Kawabata, 2007^173^ | 50 J, 100 J, 150 J, 175 J (IV amiodarone) | 100 J, 200 J, 300 J, 360 J (IV amiodarone) | 154 | – Restoration of SR after cumulative shocks; – Restoration of SR after 1st shock
Khaykin, 2003^174^ | 150 J, 200 J, 360 J | Single 360 J | 56 | – Restoration of SR
Marinsek, 2003^194^ | 70 J, 100 J, 150 J, 200 J | 100 J, 200 J, 300 J, 360 J | 83 | – Maintenance of SR at 1 month
Mortensen, 2008^196^ | 75 J, 100 J, 150 J, 200 J | 100 J, 150 J, 200 J, 300 J, 360 J | 95 | – Restoration of SR immediately after cumulative shocks; – Restoration of SR after 1st shock
Page, 2002^179^ | 100 J, 150 J, 200 J, 200 J biphasic or 360 J monophasic | 100 J, 150 J, 200 J, 200 J biphasic or 360 J monophasic | 203 | – Restoration of SR after 4 shocks; – Restoration of SR after 3 shocks; – Restoration of SR after 2 shocks; – Restoration of SR after 1 shock
Ricard, 2001^200^ | 150 J, 150 J | 150 J, 360 J | 57 | – Restoration of SR after all shocks; – Restoration of SR after 1 shock
Scholten, 2003^201^ | 120–200 J sequence | 200–360 J sequence | 277 | – Restoration of SR after 1st shock; – Restoration of SR after 2nd shock
Siaplaouras, 2004^203^ | 120 J, 150 J, 200 J, 200 J | 200 J, 300 J, 360 J, 360 J | 216 | – Restoration of SR; – Recurrence of AF within 1 minute

Abbreviations: AF=atrial fibrillation; J=Joules; N=number of patients; SR=sinus rhythm

Among the 9 studies comparing a biphasic waveform with a monophasic waveform, 8 assessed restoration of sinus rhythm at 0 or 30 minutes after cardioversion, and 1 assessed maintenance of sinus rhythm at 1 month following electrical cardioversion.194 Only two studies included only patients with persistent AF,194,203 and one study included only patients for whom a prior rate- or rhythm-control therapy was ineffecitve.174 One study also included an assessment of recurrence of AF within 1 minute following initial cardioversion.203 All but one of the studies were single-center.179 Three studies were of good quality, and six were of fair quality. Among these nine studies, mean/median population age ranged from 55–70 years; data on AF type and heart failure prevalence were generally not reported.

Four studies (393 patients) compared anterolateral vs. anteroposterior placement of the defibrillation electrodes during external electrical cardioversion.175,183,187,202 One study was of good quality,175 and three were of fair quality.183,187,202 One study was conducted in the outpatient setting;175 the other three did not specify the setting. All four studies included only patients with persistent AF. The mean age of patients receiving the anterolateral approach ranged from 58–68 years, and the mean age of patients receiving the anteroposterior approach ranged from 62–67 years. All four studies assessed restoration of sinus rhythm immediately after the external electrical cardioversion, all four were conducted in Europe, and all four were single-center studies. LVEF was reported only in three studies, and the mean ranged from 49–60 percent in those receiving the anterolateral approach and 49–59 percent in those receiving the anteroposterior approach.

Six studies assessed different external electrical cardioversion protocols for conversion of AF. In three of these (432 patients) there was a comparison between an initial monophasic energy of 200 J and 360 J.172,185,186 Two of these were single-center studies,185,186 and one was multicenter;172 two were conducted in Europe,185,186 and one in the United States.172 All three studies were composed entirely of patients with persistent AF, and all utilized monophasic waveforms with varying electrode positioning; in two, patients who did not convert with the first shock received a subsequent shock.172,186 All three studies comparing monophasic shocks of 200 J and 360 J assessed restoration of sinus rhythm immediately after the electrical cardioversion procedure. In the other three studies assessing cardioversion protocols, different biphasic energies were evaluated.171,182,198 In one of these, the different energy protocols also involved different biphasic wave shapes (truncated vs. rectilinear).182 Two of the studies were composed entirely of patients with persistent AF;171,198 the type of AF was not reported in the third study.182

A single study compared standard polarity to reverse polarity.197 This was a multicenter study in the United States and included only patients with persistent AF. The study was of fair quality; however, errors in the publication prevented collection of accurate baseline characteristics. Both biphasic and monophasic waveforms were tested, and the outcome was restoration of sinus rhythm within 30 seconds; however, statistical testing was not performed on this outcome measure.

Finally, a single study compared steel paddles to adhesive pads for electrical cardioversion.176 This study was a single-center study of good quality funded by industry and conducted in Europe. All patients were outpatients with persistent AF. A monophasic and biphasic waveform was used in both intervention arms.

##### Restoration of Sinus Rhythm

###### Biphasic Versus Monophasic Waveforms

Eight studies compared biphasic and monophasic waveforms and assessed restoration of sinus rhythm immediately or at 30 minutes after external electrical cardioversion;173,174,179,184,196,200,201,203 none of these demonstrated a statistically significant difference between the biphasic and monophasic protocols. However, among studies with analyses looking only at the first protocol-specified shock, four studies demonstrated a statistically significant greater restoration of sinus rhythm with biphasic waveforms compared with monophasic.174,179,196,200 A meta-analysis of these 4 studies representing 411 patients estimated an odds ratio (OR) of 4.39 (95% CI, 2.84 to 6.78) and demonstrated a large and statistically significant benefit of biphasic waveform for restoration of sinus rhythm compared with monophasic when looking only at the first protocol-specified shock (Figure 6; high strength of evidence). There was no evidence of heterogeneity. The Q-value was 2.85 for 3 degrees of freedom, p=0.416.

Figure 6 Forest plot for restoration of sinus rhythm for monophasic versus biphasic waveforms

Abbreviation: CI=confidence interval

This figure displays a forest plot of four studies that compared biphasic and monophasic waveforms and assessed restoration of sinus rhythm looking only at the first protocol-specified shock. The summary odds ratio was 4.389 (95% CI, 2.842 to 6.776) and demonstrated a large and statistically significant benefit of biphasic waveform for this outcome.

###### Anterolateral Versus Anteroposterior Electrical Cardioversion

In the four studies that assessed restoration of sinus rhythm in patients with persistent AF receiving external electrical cardioversion via anterolateral versus the anteroposterior electrode placement,175,183,187,202 one175 found a statistically significant greater rate of conversion to sinus rhythm with the anteroposterior placement (78% with anterolateral vs. 96% with anteroposterior; p=0.009), and one183 found a greater conversion rate with the anterolateral position (60% anterolateral vs. 34% anteroposterior; p=0.048). In the other two studies, there was no statistically significant difference between the two approaches.187,202 A meta-analysis of these 4 studies involved 393 patients and estimated an OR of 0.87 (95% CI, 0.20 to 3.72), showing no statistical difference between the two approaches (Figure 7; low strength of evidence). There was some evidence of heterogeneity (Q-value=9.60 for 3 degrees of freedom, p=0.22), reducing the overall strength of evidence.

Figure 7 Forest plot of restoration of sinus rhythm for anterolateral versus anteroposterior electrode placement

Abbreviation: CI=confidence interval

This figure displays a forest plot of four studies that assessed restoration of sinus rhythm in patients with persistent AF receiving external electrical cardioversion via antero-lateral versus the antero-posterior paddle placement. The summary odds ratio was 0.866 (95% CI, 0.202 to 3.720), showing no statistical difference between the two electrode placements.

In the two studies using monophasic waveforms,175,183 crossover to the alternative approach was specified in the protocol183 or allowed175 if there was a failure of cardioversion with the initial approach. In the study in which the crossover was specified in the protocol, there was no statistically significant difference in success with the anteroposterior second shock versus the anterolateral second shock (42% vs. 21%, p=0.22).183 In the study in which crossover to the alternative approach was allowed, 8 of 12 patients in whom the anterolateral approach failed were successfully cardioverted with the anteroposterior approach, and neither of the 2 patients in whom the anteroposterior approach failed was successfully cardioverted with the anterolateral approach.175 No statistical testing was done to compare these results.

###### Energy and Energy Protocols for External Electrical Cardioversion

The three studies that included a comparison of a 200 J monophasic initial shock to a 360 J monophasic initial shock in patients with persistent AF172,185,186 all showed a statistically significantly greater rate of restoration of sinus rhythm immediately after the shock in those receiving the 360 J shock versus the 200 J shock (95% vs. 39%, p<0.0001;^172^ 96% vs. 75%, p=0.003;^186^ and 68% vs. 42%, p<0.001^185^). A meta-analysis of these 3 studies represented 432 patients and estimated an OR of 0.16 (95% CI, 0.05 to 0.53) favoring a 360 J monophasic shock (Figure 8; high strength of evidence). There was limited evidence of heterogeneity. The Q-value was 4.99 for 2 degrees of freedom, p=0.083.

Figure 8 Forest plot of restoration of sinus rhythm for 200 J versus 360 J monophasic initial shocks

Abbreviations: CI=confidence interval; J=Joules

This figure displays a forest plot of three studies that included a comparison of a 200 J monophasic initial shock to a 360 J monophasic initial shock in patients with persistent AF. The summary odds ratio was 0.159 (95% CI, 0.047 to 0.533) and showed a statistically significantly greater rate of restoration of sinus rhythm immediately after the shock in those receiving the 360 J shock.

In two of three studies that compared different biphasic energy protocols there was no statistically significant difference between the truncated and rectilinear protocols (97% vs. 93%; p=0.44), or between a biphasic stepped and non-stepped approach (90% vs. 88%; p=0.56) in restoration of sinus rhythm.171,182 In the third study, a larger proportion of patients had restoration of sinus rhythm with the higher biphasic energy levels (7% with 20J, 23% with 50J, 63% with 100J, and 83% with 200J), but the study did not statistically assess that difference.198

In the study comparing use of standard polarity with reverse polarity using both monophasic and biphasic waveforms, 84 percent of patients with standard polarity and 78 percent with reverse polarity reverted to sinus rhythm (statistical test not provided).197

In the study comparing steel paddles with adhesive pads using both monophasic and biphasic waveforms, 96 percent of patients with the steel paddles compared with 88 percent of patients with the adhesive patches had restoration of sinus rhythm immediately following the cardioversion (p=0.04).176 Cardioversion success rate was 100 percent in the biphasic shock group with paddle electrodes (56/56 patients) but 96 percent (46/48 patients) when patches were used (p=0.07).

##### Maintenance of Sinus Rhythm

###### Biphasic Versus Monophasic Waveforms

In the study that assessed maintenance of sinus rhythm at 1 month following electrical cardioversion,194 there was no statistically significant difference between biphasic and monophasic waveforms in these patients with persistent AF (60% vs. 100%; p=0.13 for biphasic vs. monophasic; insufficient strength of evidence).

##### Recurrence of Atrial Fibrillation

###### Biphasic Versus Monophasic Waveforms

In assessing early recurrence of AF there was no statistically significant difference between the biphasic and monophasic waveform in the 1 study that assessed this outcome in patients with persistent AF (8.1% for biphasic and 9.7% for monophasic; p=NS;203 low strength of evidence).

##### Results in Specific Subgroups of Interest

Thirteen (62%) of the 21 studies that compared different methods of external electrical cardioversion included only patients with persistent AF (2 of 9 studies comparing biphasic with monophasic waveforms,194,203 all 4 studies comparing anterolateral vs. anteroposterior placement of the defibrillation electrodes,175,183,187,202 all 3 studies comparing 200 vs. 360 J monophasic shock,172,185,186 2 of the 3 studies comparing different biphasic protocols,171,198, the 1 study comparing standard polarity to reverse polarity,197 and the 1 study comparing steel paddles to adhesive pads176). As expected, methods of external electrical cardioversion would be most relevant to patients with persistent AF, and therefore, the majority of studies focused primarily on this subgroup of interest. The results of these studies therefore may not be applicable to patients with permanent AF and are potentially applicable only to subsets of patients with paroxysmal AF. Of the eight studies that were not categorized as including only patients with persistent AF, seven did not provide information on type of AF,173,174,179,182,184,196,201 and one200 had seven percent of patients with paroxysmal AF; the proportion of patients with other types of AF were not reported. Therefore, comparisons in results by type of AF could not be made.

#### Drug Enhancement of External Electrical Cardioversion

##### Overview

Four studies evaluated the use of external electrical cardioversion alone in comparison with external electrical cardioversion augmented by drug treatment (metoprolol,178 verapamil,199,205 and ibutilide195). The general objective of these studies was to determine if drug pretreatment improves the outcome of external electrical cardioversion. A total of 329 patients were included in these studies; 3 studies included only patients with persistent AF.178,195,199 One study was rated as good quality,178 two were fair quality,195,199 and one was poor quality.205 All four studies were conducted in Europe, and three were single-center;178,195,205 the number of sites was not reported in the fourth study.199 In the two studies using verapamil, verapamil was given 3 days before and 3 days after electrical cardioversion.199,205 Ibutilide was given about 20 minutes before electrical cardioversion,195 and metoprolol was titrated over an unspecified time period prior to electrical cardioversion.178 Placebo was administered to patients in the electrical cardioversion arm only in the study that assessed metoprolol pretreatment.178 Mean age of patients ranged from 60–69 years in the drug-enhanced arms and from 60–68 years in the electrical cardioversion only arms. LVEF was reported in three studies178,195,205 and ranged from 49–53 percent in the drug arms and from 50–53 percent in the electrical cardioversion alone arm. Restoration of sinus rhythm immediately after electrical cardioversion was reported in two studies.178,195 Maintenance of sinus rhythm 1 week after electrical cardioversion was assessed in two studies,178,199 and recurrence of AF at 1 week was reported in one poor-quality study.205

##### Restoration of Sinus Rhythm

Two of the four studies included a measure of restoration of sinus rhythm following the electrical cardioversion procedure. Both studies included only patients with persistent AF. One compared external electrical cardioversion with ibutilide pretreatment versus electrical cardioversion without ibutilide pretreatment.195 In this study 100 percent of patients in both groups had sinus rhythm restored immediately after electrical cardioversion. Adverse events were not reported. In a second study,178 restoration of sinus rhythm immediately after cardioversion was compared among patients receiving metoprolol pretreatment and patients receiving placebo pretreatment. Ninety-five percent of patients with metoprolol pretreatment converted to sinus rhythm compared with 93 percent of patients without metoprolol pretreatment (no p-value reported; moderate strength of evidence).

##### Maintenance of Sinus Rhythm

Two of the four studies assessed maintenance of sinus rhythm at 1 week following external electrical cardioversion. In one study comparing metoprolol pretreatment with no pretreatment,178 a greater proportion of patients with metoprolol pretreatment maintained sinus rhythm at 1 week than did patients without metoprolol pretreatment (55% vs. 40%; p=0.04). Two patients in the metoprolol group developed bradycardia, and 10 percent and 9 percent, respectively, developed vertigo or dizziness in the metoprolol and no metoprolol groups. In the second study,199 verapamil pretreatment was compared with no verapamil pretreatment in 23 patients with persistent AF. Eight of 9 patients (89%) receiving verapamil pretreatment maintained sinus rhythm at 1 week compared with 6 of 14 patients (43%) not receiving verapamil pretreatment (p=0.027). There was significant benefit for patients given verapamil or metoprolol pretreatment (moderate strength of evidence). Adverse events were not reported.

##### Recurrence of Atrial Fibrillation

One poor-quality study reported recurrence of AF within the first week after electrical cardioversion in patients with and without verapamil pretreatment.205 In this study 3 percent of patients with verapamil pretreatment compared with 11 percent without verapamil pretreatment had recurrent AF within 1 week following cardioversion (p=0.02; low strength of evidence). Adverse events were not reported.

##### Results in Specific Subgroups of Interest

As described above, three of the four studies included patients with only persistent AF. As with the overall results, no definitive conclusions can be drawn for this subgroup of interest because of the small number of patients and different drug treatments used in the studies. Other specific subgroups of interest were not explored within the included studies.

#### Comparison of Drugs for Pharmacologic Cardioversion

##### Overview

Seventeen studies including 2,455 patients compared 2 or more rate- or rhythm-control drugs and assessed conversion of AF to sinus rhythm.140,144,145,147,149,170,177,180,181,188-193,204,206 Six studies were multicenter,145,147,180,189,190,206 nine were single-center,140,144,149,170,177,188,191-193 and in two the number of sites was not reported.181,204 Twelve studies were conducted in Europe,140,144,145,147,170,177,188,191-193,204,206 two in Australia/New Zealand,149,190 one in the UK,181 and two in the United States.180,189 Five studies were of good quality,140,170,177,180,181 11 of fair quality,144,145,147,149,188-193,204 and 1 of poor quality.206 Three studies were conducted in an inpatient setting,140,144,177 three in an outpatient setting,147,180,192 four in the emergency room,149,170,189,190 one in multiple settings,188 and in six the setting was not reported.145,181,191,193,204,206 Two studies received industry funding,145,180 1 received government funding,180 4 were funded by nongovernment, nonindustry sources,145,149,177,189 and 12 did not report funding source.140,144,147,170,181,188,190-193,204,206 Nine studies included only patients with persistent AF,144,145,147,170,177,192,193,204,206 and one included only patients with paroxysmal AF.189

Only seven of the studies included a comparison between two or more antiarrhythmic drugs (Table 11).149,170,177,180,181,190,191 The most common comparison was between amiodarone and sotalol (four studies). Amiodarone was compared with ibutilide in one study and with flecainide and propafenone in one study, and ibutilide was compared with propafenone plus ibutilide in one study. Three of the studies included placebo170,180 or control181 arms which were not included in our analyses. Two of these studies also included an additional intervention arm that evaluated the use of digoxin.149,190 In four studies, electrical cardioversion was not part of the study protocol, while in the remaining three the effect of the drugs was evaluated before and after external electrical cardioversion. Restoration of sinus rhythm was assessed prior to electrical cardioversion within 12 hours of drug administration in 1 of these 3 studies,149 within 28 days in the second study,180 and within 6 weeks of drug initiation in the third.181 In the studies without use of electrical cardioversion, restoration of sinus rhythm was assessed at 48 hours in one study and within 24 hours in the other three studies. In addition, one study assessed recurrence of AF within 24 hours.177 Two of the studies were conducted primarily in an emergency room setting,149,170 two in an inpatient setting,177,191 and three in an outpatient setting.180,181,190

Table 11 Studies including comparisons between antiarrhythmic drugs

Study | Sample Size (N) | Arm 1 | Arm 2 | Arm 3 | Timing of Outcome Assessment Prior to or Without DCC | Assessment of Conversion Post-DCC?
Thomas, 2004^149^ | 140 | Amiodarone (IV then oral) | Sotalol (IV then oral) | Digoxin (IV then oral) | Within 12 hours | Yes
Vijayalakshmi, 2006^181^ | 94 | Amiodarone (oral) | Sotalol (oral) | Control^a^ | Within 6 weeks | Yes
Singh, 2005^180^ | 665 | Amiodarone (oral) | Sotalol (oral) | - | 28 days | Yes
Joseph, 2000^190^ | 115 | Amiodarone (IV then oral) | Sotalol (IV then oral) | Digoxin (IV then oral) | 48 hours | No
Balla, 2011^170^ | 160 | Amiodarone (oral) | Flecainide (oral) | Propafenone (oral) | Within 24 hours | No
Kafkas, 2007^191^ | 152 | Amiodarone (IV) | Ibutilide (IV) | - | Within 24 hours | No
Korantzopoulos, 2006^177^ | 100 | Ibutilide (IV) | Propafenone (oral) + ibutilide (IV) | - | Within 24 hours Also assessed recurrence within 24 hours post-conversion | No

a Not included in analyses.

Abbreviations: DCC=direct current cardioversion

In 8 studies (including 2 from Table 11), an antiarrhythmic drug (amiodarone, sotalol, or ibutilide) was compared with a rate-controlling drug (digoxin, diltiazem, carvedilol, or esmolol). Among these, restoration of sinus rhythm was assessed both before and after electrical cardioversion in three studies.144,149,204 In the remaining five studies, external electrical cardioversion was not part of the study protocol.140,188,190,192,193 In those studies, restoration of sinus rhythm was assessed from 30 minutes to 48 hours following drug initiation. In addition, 1 of the studies reported recurrence of AF within 24 hours of drug treatment and electrical cardioversion.144

In four studies, rate-controlling drugs were used in both study arms, and the study assessed restoration of sinus rhythm. In three of these, restoration of sinus rhythm was assessed before and after electrical cardioversion.145,147,206 In the remaining study, restoration of sinus rhythm was assessed during the period of drug infusion (esmolol vs. digoxin).189 In addition, one of the studies also assessed recurrence of AF at 1 month following conversion.206

##### Restoration of Sinus Rhythm

Results for comparisons between antiarrhythmic drugs are shown in Table 12. No statistically significant differences among the drugs were seen except between amiodarone versus ibutilide in one study and between ibutilide plus propafenone versus ibutilide alone in one study. Few adverse events were reported in any of the studies.

Table 12 Comparisons of antiarrhythmic drugs for restoration of sinus rhythm

Study | Sample Size (N) | Time Frame for Assessment | Restoration of SR pre-DCC (or Without DCC) | P Value | Restoration of SR Post-DCC | P value
Thomas, 2004^149^ | 140 | 12 hours | Amiodarone: 27/52 (52%) Sotalol: 20/45 (44%) Digoxin: 21/42 (50%) | NS | Amiodarone: 22/25 (88%) Sotalol: 23/25 (92%) Digoxin: 20/21 (95%) | NR
Vijayalakshmi, 2006^181^ | 94 | 6 weeks | Amiodarone: 7/27 (26%) Sotalol: 7/31 (23%) | 0.5 | Amiodarone: 15/20 (75%) Sotalol: 26/28 (93%) | NS
Joseph, 2000^190^ | 115 | 48 hours | Amiodarone: 30/39 (77%) Sotalol: 35/40 (88%) Digoxin: 21/36 (58%) | <0.01, sotalol vs. digoxin; NR between other drugs | NA | NA
Singh, 2005^180^ | 665 | 28 days | Amiodarone: 70/258 (27%) Sotalol: 59/244 (24%) | 0.45 | Amiodarone: 72% Sotalol: 74% | NR
Balla, 2011^170^ | 160 | 24 hours | Amiodarone: 85% Flecainide: 88% Propafenone: 85% | NS | NA | NA
Kafkas, 2007^191^ | 152 | 24 hours | Amiodarone: 42/73 (58%) Ibutilide: 63/79 (80%) | 0.005 | NA | NA
Korantzopoulos, 2006^177^ | 100 | 24 hours | Ibutilide: 21/51 (41%) Propafenone + ibutilide: 35/49 (84%) | 0.004 | NA | NA

Abbreviations: DCC=direct current cardioversion; N=number of participants; NA=not applicable; NR=not reported; NS=not statistically significant; SR=sinus rhythm

We performed a meta-analysis of the four studies that compared amiodarone and sotalol.149,180,181,190 These studies represented 736 patients and estimated an OR of 1.12 (95% CI, 0.81 to 1.56), demonstrating a potential benefit of amiodarone compared with sotalol which did not reach statistical significance (Figure 9; low strength of evidence). There was no evidence of heterogeneity. The Q-value was 2.22 for 3 degrees of freedom, p=0.527.

Figure 9 Forest plot for restoration of sinus rhythm for amiodarone versus sotalol

Abbreviation: CI=confidence interval

This figure displays a forest plot of four studies that compared amiodarone with sotalol for restoration of sinus rhythm. The summary odds ratio was 1.120 (95% CI, 0.805 to 1.559) demonstrating a potential benefit of amiodarone for restoration of sinus rhythm as compared with sotalol, but this benefit was not statistically significant.

Eight studies compared an antiarrhythmic drug to a rate-controlling drug (one study compared an antiarrhythmic drug to the same antiarrhythmic drug used with a rate-controlling drug188) and assessed restoration of sinus rhythm from 30 minutes to 6 weeks after drug initiation (Table 13). Two of these included a second antiarrhythmic drug arm.149,190 Three studies reported a statistically significantly greater restoration in sinus rhythm with amiodarone versus a rate-controlling drug, three studies showed no statistically significant difference between amiodarone and the rate-controlling drug, and one did not report a statistical analysis comparing amiodarone with a rate-controlling drug. One study showed that sotalol was better than digoxin at restoring sinus rhythm (88% vs. 58%; p<0.01), and another showed that esmolol plus ibutilide was better than ibutilide alone (OR 2.50; 95% CI, 1.04 to 5.84). Three studies evaluated differences between an antiarrhythmic drug and rate-controlling drug in rates of conversion after an electrical cardioversion. In 1 study amiodarone had a greater rate of conversion than diltiazem or digoxin (91% for amiodarone, 76% for diltiazem, and 67% for digoxin) which was statistically significant, but the other 2 studies either found no statistically significant difference or did not report a statistical analysis.

Table 13 Studies including comparisons of an antiarrhythmic drug with a rate-controlling drug

Study | Sample Size (N) | Time Frame for Assessment | Restoration of SR pre-DCC (or Without DCC) | P Value | Restoration of SR Post-DCC | P Value
Thomas, 2004^149^ | 140 | 12 hours | Amiodarone: 27/52 (52%) Sotalol: 20/45 (44%) Digoxin: 21/42 (50%) | NS | Amiodarone: 22/25 (88%) Sotalol: 23/25 (92%) Digoxin: 20/21 (95%) | NR
Joseph, 2000^190^ | 115 | 48 hours | Amiodarone: 30/39 (77%) Sotalol: 35/40 (88%) Digoxin: 21/36 (58%) | <0.01, sotalol vs. digoxin; NR between other drugs | NA | NA
Capucci, 2000^144^ | 61 | 1 month | Amiodarone: 25% Diltiazem: 3% | 0.005 | Amiodarone: 20/23 (87%) Diltiazem: 19/29 (66%) | NS
Villani, 2000^204^ | 120 | 1 month | Amiodarone: 25% Diltiazem: 6% Digoxin: 3% | 0.005, amiodarone vs. digoxin | Amiodarone: 91% Diltiazem: 76% Digoxin: 67% | 0.05, amiodarone vs. diltiazem and amiodarone vs. digoxin
Manios, 2003^193^ | 106 | 6 weeks | Amiodarone: 4/34 (12%) Diltiazem: 2/33 (6%) | NR | NA | NA
Kanoupakis, 2004^192^ | 142 | 4 weeks | Amiodarone: 3/48 (6%) Carvedilol: 1/48 (2%) | NR | NA | NA
Hofmann, 2006^140^ | 100 | 30 minutes | Amiodarone: 28% Digoxin: 6% | 0.003 | NA | NA
Fragakis, 2009^188^ | 90 | 90 minutes | Ibutilide + esmolol vs. Ibutilide alone | OR: 2.50 (95% CI, 1.04 to 5.84) | NA | NA

Abbreviations: CI=confidence interval; DCC=direct current cardioversion; N=number of participants; NA=not applicable; NR=not reported; NS=not statistically significant; OR=odds ratio; SR=sinus rhythm

We performed a meta-analysis of the 7 studies that compared amiodarone with a rate-controlling drug. This analysis of 613 patients estimated an OR of 2.99 (95% CI, 1.64 to 5.44), demonstrating a statistically significant benefit of amiodarone compared with rate-controlling drugs for restoration of sinus rhythm (Figure 10; high strength of evidence). There was no evidence of heterogeneity. The Q-value was 9.99 for 7 degrees of freedom, p=0.189. This finding is unsurprising given that rate-controlling agents would not be expected to terminate sinus rhythm.

Figure 10 Forest plot for restoration of sinus rhythm for amiodarone versus rate-control drugs

Abbreviation: CI=confidence interval

This figure displays a forest plot of seven studies that compared amiodarone with a rate-control drug for restoration of sinus rhythm. The summary odds ratio was 2.990 (95% CI, 1.644 to 5.440), demonstrating a statistically significant benefit of amiodarone for this outcome.

Four studies compared a rate-controlling drug with another rate-controlling drug and assessed restoration of sinus rhythm. In three of the studies, a comparison between drugs was also made after an external electrical cardioversion procedure.145,147,206 Three of the studies compared verapamil to digoxin for 2–4 weeks,145,147,206 and one compared IV esmolol to digoxin189 during the infusion period. In three of the studies no difference was found between the drugs in the proportion of patients converting to sinus rhythm.145,189,206 In 1 study, 14 percent of patients receiving verapamil converted to sinus rhythm compared with 0 percent receiving digoxin, a difference that was statistically significant (p<0.05).147 In the three studies that also assessed outcomes after electrical cardioversion, only one found a statistically significant difference between the treatment arms; this favored digoxin over verapamil (65% of patients receiving verapamil vs. 88% of patients receiving digoxin converted to sinus rhythm; p<0.05).147

##### Recurrece of Atrial Fibrillation

Recurrence of AF within 24 hours of drug initiation was reported in 1 study that compared antiarrhythmic drugs (amiodarone vs. ibutilide).191 In this study, 7.1 percent of patients receiving amiodarone versus 7.9 percent of patients receiving ibutilide had recurrence of AF with 24 hours (p=NS; low strength of evidence).

##### Results in Specific Subgroups of Interest

No results were reported for outcomes of interest in specific subgroups of interest.

### Strength of Evidence

Our review identified 42 studies exploring the use of antiarrhythmic drugs and electrical cardioversion for conversion to sinus rhythm. These studies demonstrated that a single biphasic waveform is more effective than monophasic waveform in patients with persistent AF. Conversely, the included studies did not identify a significant difference in restoration of sinus rhythm with use of an anterolateral versus anteroposterior positioning of cardioversion electrodes. Although the strength of this evidence was rated as low, this finding is potentially clinically helpful, as health care providers often debate the superiority of one positioning of cardioversion electrodes over another. Studies demonstrated a benefit of drug pretreatment for restoration and maintenance of sinus rhythm, although data were inconclusive as to whether specific drugs were more beneficial as compared to other pharmacological alternatives. This finding challenges the assumption that one antiarrhythmic medication is clearly superior to others and underscores the need for more studies comparing the effectiveness and safety of different antiarrhythmic medications in enhancing restoration of sinus rhythm. Table 14 summarizes the strength of evidence for the outcomes of interest comparing antiarrhythmic drugs and electrical cardioversion methods. For those comparisons where the number of studies was sufficient to estimate a summary effect we were able to have greater confidence in our findings.

Table 14 Strength of evidence domains for antiarrhythmic drugs versus electrical cardioversion

Outcome | Number of Studies (Subjects) | Domains Pertaining to SOE | | | | SOE and Magnitude of Effect (95% CI)
Outcome | Number of Studies (Subjects) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect (95% CI)
Comparison of Various Methods for External Electrical Cardioversion (Biphasic vs. Monophasic Waveforms)
Restoration of Sinus Rhythm | 4 (411) | RCT/Low | Consistent | Direct | Precise | SOE=High OR 4.39 (95% CI, 2.84 to 6.78) favoring biphasic waveform
Maintenance of Sinus Rhytm | 1 (83) | RCT/Moderate | NA | Direct | Imprecise | SOE=Insufficient
Recurrence of AF | 1 (216) | RCT/Low | NA | Direct | Imprecise | SOE=Low No difference
Comparison of Various Methods for External Electrical Cardioversion (Anterolateral vs. Anteroposterior Cardioversions)
Restoration of Sinus Rhythm | 4 (393) | RCT/Low | Inconsistent | Direct | Imprecise | SOE=Low OR 0.87 (95% CI, 0.20 to 3.72) showing potential benefit of anterolateral electrode placement which did not reach statistical significance
Comparison of Various Methods for External Electrical Cardioversion (Energy Protocols)
Restoration of Sinus Rhythm | 3 (432) | RCT/Low | Consistent | Direct | Precise | SOE=High OR 0.16 (95% CI, 0.05 to 0.53) favoring 360 J vs. 200 J monophasic shock
Drug Enhancement of External Electrical Cardioversion (vs. No Drug Enhancement)
Restoration of Sinus Rhythm | 2 (218) | RCT/Low | Consistent | Direct | Imprecise | SOE=Moderate No significant benefit for patients given ibutilide or metoprolol pretreatment (p values NR)
Maintenance of Sinus Rhytm | 2 (195) | RCT/Low | Consistent | Direct | Imprecise | SOE=Moderate Significant benefit for patients given verapamil or metoprolol pretreatment (p values of 0.04 and 0.027 in the 2 studies)
Recurrence of AF | 1 (88) | RCT/Moderate | NA | Direct | Precise | SOE=Low Significant benefit of verapamil pretreatment (p=0.02)
Comparison of Drugs for Pharmacological Cardioversion (Amiodarone vs. Sotalol)
Restoration of Sinus Rhythm | 4 (736) | RCT/Low | Inconsistent | Direct | Imprecise | SOE=Low OR 1.12 (95% CI, 0.81 to 1.56) demonstrating a potential benefit of amiodarone which did not reach statistical significance
Comparison of Drugs for Pharmacological Cardioversion (Amiodarone vs. Rate-Control Drugs)
Restoration of Sinus Rhythm | 7 (613) | RCT/Low | Consistent | Direct | Precise | SOE=High OR 2.99 (95% CI, 1.64 to 5.44) demonstrating a significant benefit of amiodarone
Recurrence of AF | 1 (152) | RCT/Low | NA | Direct | Imprecise | SOE=Low No difference between amiodarone vs. ibutilide within 24 hours

Abbreviations: AF=atrial fibrillation; CI=confidence interval; OR=odds ratio; NA=not applicable; NR=not reported; RCT=randomized controlled trial; SOE=strength of evidence

## Key Question 5 Rhythm-Control Procedures and Drugs for Maintenance of Sinus Rhythm

KQ 5: What are the comparative safety and effectiveness of newer procedural rhythm-control therapies, other nonpharmacological rhythm-control therapies, and pharmacological agents (either separately or in combination with each other) for maintenance of sinus rhythm in atrial fibrillation patients? Do the comparative safety and effectiveness of these therapies differ among specific patient subgroups of interest?

### Key Points

Procedural therapies
- Transcatheter pulmonary vein isolation (PVI) versus antiarrhythmic drugs
  ○ Based on 8 RCTs (5 good, 3 fair quality) involving 921 patients, transcatheter PVI is superior to antiarrhythmic drugs for maintenance of sinus rhythm over 12 months of followup in patients with paroxysmal AF (high strength of evidence). This evidence is strongest in younger patients with little to no structural heart disease, and with no or mild enlargement of the left atrium.
  ○ Based on 2 RCTs (both good quality) involving 268 patients, transcatheter PVI is superior to antiarrhythmic medications in reducing cardiovascular hospitalizations (moderate strength of evidence).
- Transcatheter PVI with complex fractionated atrial electrogram (CFAE) ablation versus transcatheter PVI without CFAE ablation
  ○ Based on 9 RCTs (6 good, 3 fair quality) involving 817 patients, CFAE ablation done in addition to transcatheter PVI showed a potential benefit in the maintenance of sinus rhythm at 12 months compared with PVI alone which did not reach statistical significance (low strength of evidence).
- Surgical Maze versus standard of care (mitral valve surgery)
  ○ Based on 7 RCTs (1 good, 6 fair quality) involving 361 patients, surgical Maze at the time of other cardiac surgery (specifically mitral valve surgery) is superior to mitral valve surgery alone for maintenance of sinus rhythm over at least 12 months of followup in patients with persistent AF (moderate strength of evidence).
- PVI done at the time of cardiac surgery versus cardiac surgery alone or cardiac surgery in combination with antiarrhythmic drugs (AADs) or catheter ablation
  ○ Based on 8 RCTs (5 good, 3 fair quality) involving 532 patients, PVI done at the time of cardiac surgery is superior to cardiac surgery alone or cardiac surgery in combination with AADs or catheter ablation for maintenance of sinus rhythm over 12 months of followup in patients with persistent AF (high strength of evidence).
- All comparisons
  ○ There are insufficient data on the effect of rhythm control with PVI or surgical Maze on final outcomes such as all-cause mortality, stroke, heart failure, and LVEF, and on the safety and durability of the effectiveness of these procedures beyond 12 months.

Pharmacological therapies
- Based on 9 studies (1 good, 8 fair quality) involving 2,095 patients, amiodarone appears better than sotalol but no different from propafenone in maintaining sinus rhythm (low strength of evidence).
- Based on 10 studies (4 good, 6 fair quality) involving 3,223 patients, amiodarone appears better than dronedarone or sotalol but no different from propafenone in reducing AF recurrence (low strength of evidence).
- Only 1 fair-quality study, a substudy of the AFFIRM (Atrial Fibrillation Follow-Up Investigation of Rhythm Management) study involving 256 patients, systematically assessed differences in all-cause mortality between AADs; it found no statistically significant difference after a mean followup of 3.8 years between those receiving amiodarone versus sotalol (insufficient strength of evidence).
- Based on 1 good-quality study of 403 patients, amiodarone lowered AF hospitalizations compared with sotalol or propafenone (low strength of evidence) but did not demonstrate a benefit in control of AF symptoms (low strength of evidence).
- Based on 2 good-quality studies involving 1,068 patients, there was no difference among agents in impact on quality of life (low strength of evidence).

### Overall Description of Included Studies

A total of 83 studies met our inclusion criteria and assessed the comparative safety and effectiveness of new procedural rhythm-control therapies, other nonpharmacological rhythm-control therapies, and pharmacological agents for the maintenance of sinus rhythm in patients with AF (Appendix Table F-5). Studies began enrollment from 1994 to 2007 and enrolled between 22 and 665 patients per study, resulting in a total of 11,014 patients. All were RCTs, with 36 rated as being of good quality,178,180,181,207-239 43 fair quality,144,145,240-280 and 4 poor quality.205,281-283

A majority of studies (53 [64%]) were single-center trials,144,178,205,207,210,211,213,214,216-219,221,226,229,231,233,234,240,242-248,250,252,254,255,257-271,274-278,280,281,283 while 23 were multicenter trials,145,180,208,209,212,215,220,222-225,227,228,230,232,235,236,241,249,253,256,272,273 and 7 were not clear regarding the number of study sites.181,237-239,251,279,282 A majority of studies (54 [65%] included sites in Europe,144,145,178,181,205,207-215,219-228,232-237,242,244,245,247,249-251,253-256,258-261,265,269,270,273-275,280-282 22 included sites in North America,180,215-218,220,223-225,228-230,236,241,253,256,266,267,271,276,277,279 10 included sites in Asia,224,231,238,246,257,262-264,278,283 5 included sites in South America,224,240,243,248,268 2 included sites in Australia;224,252 and 2 studies did not report a location.239,272 A majority of studies (51 [61%]), did not report their source of funding.144,181,205,207,208,210,211,213-216,220,222,223,226,229,231,234,238-240,242,244,245,248-253,255-261,268-272,274-277,279-283 Fourteen report that at least a component of their funding came from industry,145,178,180,209,217,218,224,228,232,236,237,241,265,273 and 10 reported that part of their funding came from government sources;180,212,221,227,230,241,243,263,264,278 15 reported other funding sources including primarily nongovernmental agencies.145,178,209,219,225,227,233,235,243,246,247,254,262,266,267

Six of the 83 included studies145,180,214,226,228-230 had secondary publications with additional relevant data which we used. Three of these six studies were multicenter trials; the other three were single-center trials. Linked/secondary papers used in the analyses below were:

- Atwood, 2007;^284^ Batcher, 2007;^285^ and Singh, 2009^286^ – all linked to Singh, 2005^180^ (SAFE-T)
- Dorian, 2003;^287^ Dorian, 2002;^288^ and Lumer, 2002^289^ – all linked to Roy, 2000^230^ (Canadian Trial of Atrial Fibrillation)
- Khargi, 2001^290^ – linked to Deneke, 2002^214^
- Leong-Sit, 2011^291^ – linked to Roux, 2009^229^ (5A)
- Pappone, 2011^292^ – linked to Pappone, 2006^226^ (APAF)
- Reynolds, 2010^293^ – linked to Wilber, 2010^228^ (ThermoCool AF)]

Below we provide an overview and then detailed syntheses stratified by the comparisons evaluated in the 83 studies.

### Procedural Therapies for Rhythm Control

#### Description of Studies

We identified 65 studies of procedural therapies for rhythm control. All were RCTs published between 2000 and 2012. They enrolled 6,739 patients across 5 continents, with the majority (36 studies) including sites in Europe. Thirty-one studies were rated as good quality,207-223,225-229,231-239 32 as fair quality,240,242-244,246-248,250-255,257,262-268,270-280 and 2 as poor quality.282,283 Sixteen studies were multicenter,208,209,212,215,220,222,223,225,227,228,232,235,236,253,272,273 43 were single-center,207,210,211,213,214,216-219,221,226,229,231,233,234,240,242-244,246-248,250,252,254,255,257,262-268,270,271,274-278,280,283 and 6 did not specify the number of sites.237-239,251,279,282 The majority of studies (39 [59%]) did not report their funding source.207,208,210,211,213-216,220,222,223,226,229,231,234,238-240,242,244,248,250-253,255,257,268,270-272,274-277,279,280,282,283 Five were reported as exclusively government funded;212,221,263,264,278 2 were a combination of government and nongovernment/non-industry funded;227,243 and 10 were reported as nongovernment/nonindustry funded alone.219,225,233,235,246,247,254,262,266,267 Eight studies were exclusively industry funded,217,218,228,232,236,237,265,273 and one study reported both industry and nongovernment funding.209 The majority of studies (38 [58%]) did not report the clinical setting.207,209,211,213-222,227,231-234,238,239,243,244,246-248,250,264,266,270-274,277,279,280,282,283 Thirteen studies were conducted in an inpatient setting,208,212,229,235,237,240,242,254,263,265,267,268,275 nine were conducted in an outpatient setting,210,226,251-253,255,257,276,278 and five were both inpatient and outpatient.223,225,228,236,262

Fourteen studies included patients from the United States,215-218,220,223,225,228,229,266,267,271,276,277 four included the UK,219,223,237,254 six included Canada,215,220,223,228,236,253 nine included Asia,231,238,246,257,262-264,278,283 four included South America,240,243,248,268 and one included Australia/New Zealand;252 three studies did not report their locations.239,272,279 Thirty-six studies included patients from Europe.207-215,220-223,225-228,232-236,242,244,247,250,251,253,255,265,270,273-275,280,282

Several studies focused on specific populations. Eleven included only patients with long-standing persistent AF,208,214,219,220,231,238,243,248,268,276,277 17 included only patients with paroxysmal AF,210,213,215,217,218,221,226,242,246,251,253,255,257,278-280,283 and 4 included only patients with persistent AF.212,216,225,240 Finally, two studies enrolled only patients with comorbid heart failure.240,264

Figure 11 represents the treatment comparisons evaluated for this KQ.

Figure 11 Overview of procedural treatment comparisons evaluated for KQ 5^a^ a Lines running from one oval back to the same oval (e.g., “Transcatheter PVI (varying type of catheter)” oval) indicate intraclass comparisons (e.g., comparison of one transcatheter PVI catheter with another). Numbers refer to numbers of comparisons.

Abbreviations: AAD(s)=antiarrhythmic drug(s); CFAE=complex fractionated atrial electrogram; CTI=cavotricuspid isthmus; KQ=Key Question; PVI=pulmonary vein isolation

This figure shows the number of comparisons between treatments evaluated in KQ 5. The most common type of comparative study was one type of transcatheter ablation/PVI procedure compared with another. There were 38 such studies. An additional eight studies compared transcatheter ablation/PVI versus antiarrhythmic drugs (AADs). Two studies compared AADs after PVI with no AADs after PVI. Seventeen studies focused on surgical procedures for rhythm control: nine of these compared concomitant surgical ablation versus cardiac surgery without ablation, and eight compared concomitant surgical Maze procedure versus surgery without Maze.

Thirty-eight studies compared one type of transcatheter ablation/PVI procedure with another.207,210,211,213,215-218,220,221,223,227,233,236,238,239,244,246,247,250-252,255,257,264-267,271,272,275-280,282,283 An additional eight studies compared transcatheter ablation/PVI with antiarrhythmic drugs (AADs).222,225,226,228,232,253,262,273 Finally, two studies compared AADs after PVI with no AADs after PVI.229,234 Seventeen studies focused on surgical procedures for rhythm control: nine of these compared concomitant surgical ablation versus cardiac surgery without ablation;208,209,212,219,235,237,268,270,274 and eight compared concomitant surgical Maze procedure versus surgery without Maze or versus transcatheter/PVI ablation.214,231,240,242,243,248,254,263

The most commonly reported outcome in the included studies was maintenance of sinus rhythm: 46 studies reported this outcome.207-210,212-223,225,226,229,233,235,236,238,240,242-244,247,250-255,257,263-265,271,274-277,279,280,282 The second most commonly reported outcome (20 studies) was recurrence of AF.210,211,216,221,222,227,232,234,239,243,246,248,257,262,264,266,268,270,272,273 Fifteen studies reported on restoration of sinus rhythm.212,214,215,219,220,231,237,238,243,266-268,278,279,283 Other outcomes reported were all-cause mortality in 12 studies,212,214,218,221,225,231,238,240,242,243,248,274 and cardiovascular mortality in 1 study.219 Five studies reported incidence of stroke,217,220,238,239,248 five reported mixed embolic events,216,222,242,273,275 and three reported bleeding events including hemorrhagic stroke.212,243,273 AF symptom control was reported in eight studies,214,228,253-255,262,271,275 and heart failure symptom control in one study.214 Cardiovascular hospitalization was reported in two studies,222,226 and hospitalization related to AF in two studies.229,273 Finally, quality of life and functional status were reported in 10 studies.219,222,223,226,228,235,242,254,262,273 Control of ventricular rate was reported in one study.253 Three studies reported composite outcomes.212,213,229

#### Detailed Synthesis

##### Transcatheter PVI Versus Antiarrhythmic Drugs

###### Overview

We identified eight RCTs for this comparison,222,225,226,228,232,253,262,273 and the available data were deemed appropriate for a meta-analysis only for only the maintenance of sinus rhythm outcome. Results for other outcomes are described qualitatively below.

###### Maintenance of Sinus Rhythm

All eight studies evaluated this outcome.222,225,226,228,232,253,262,273 A meta-analysis of these 8 studies included 921 patients and estimated an OR of 6.51 (95% CI, 3.22 to 13.16) favoring transcatheter PVI over antiarrhythmic drugs in the maintenance of sinus rhythm (Figure 12; high strength of evidence). There was significant heterogeneity. The Q-value was 32.36 for 7 degrees of freedom, p<0.001. The consistency of the findings in terms of the benefit of transcatheter PVI, however, reduced our concern with this heterogeneity, and we therefore did not reduce our strength of evidence rating.

Figure 12 Forest plot of maintenance of sinus rhythm for PVI versus drug therapy

Abbreviations: CI=confidence interval; PVI=pulmonary vein isolation

This figure displays a forest plot of eight studies that looked at the impact of transcatheter PVI versus rhythm control using pharmacological agents on maintenance of sinus rhythm. The summary odds ratio was 6.513 (95% CI, 3.224 to 13.156) favoring transcatheter PVI for this outcome.

###### All-Cause Mortality

Only one study reported on all-cause mortality.225 During 12 months of followup, 1 out of 69 (1.4%) patients in the PVI arm died versus no patients in the AAD arm (insufficient strength of evidence).

###### CV Hospitalizations

Two studies reported generally on CV hospitalizations during 12 months of followup.222,226 In one,226 24 CV hospitalizations occurred in the 99 patients who underwent PVI versus 167 in the 99 patients who received AADs (p<0.001). In the second,222 8.6 percent of patients who underwent PVI were hospitalized for a CV cause vs. 34.3 percent of patients who received an AAD (p=0.01) (moderate strength of evidence).

One study reported more specifically on AF hospitalizations.273 During 12 months of followup the rate of AF hospitalization was significantly higher in the AAD arm (15 out of 35) than in the PVI arm (3 out of 32; p<0.001) (insufficient strength of evidence).

###### Quality of Life/Functional Status

Six studies evaluated the impact of transcatheter PVI versus antiarrhythmic drugs on quality of life or functional status.222,226,253,262,273,293 The metrics for assessing these outcomes were too variable to allow quantitative synthesis, but of the six studies, four demonstrated a statistically significant better quality of life or functional status in the PVI group.222,253,273,293 The other two studies, which represented both the smallest (30 patients) and largest (198 patients) studies, did not demonstrate significant differences.226,262 Given the inconsistency in metrics and findings amongst the good-quality studies,222,226,293 we were unable to estimate the direction of impact of transcatheter PVI versus antiarrhythmic drugs on quality of life or functional status (insufficient strength of evidence).

###### Mixed Embolic Events Including Stroke

Only two studies222,273 reported on mixed embolic events including stroke. In both studies, no embolic events occurred in the PVI arm or the AAD arm during 12 months of followup (low strength of evidence).

###### Bleeding Events

Only one study reported on bleeding events.273 During 1 year of followup, there was no significant difference in the rate of bleeding between the PVI group (2 out of 32) and the AAD arm (1 out of 35; p=0.60) (insufficient strength of evidence).

###### Other Outcomes

None of these studies reported on cardiovascular mortality, or restoration of sinus rhythm, cardiovascular mortality, or heart failure symptoms.

###### Adverse Events

In one study,262 PVI resulted in one stroke and one groin hematoma, while amiodarone caused the following adverse effects in 7 patients (46.7%): GI adverse effects (mostly nausea) in 6 patients, corneal deposits in 2 patients, hypothyroidism in 2 patients, abnormal liver enzymes in 2 patients, hyperthyroidism in 1 patient, and sinus node dysfunction in 1 patient.

In one study,273 there were no thromboembolic events (defined as transient ischemic events, stroke, deep vein thrombosis, or pulmonary embolism) in either treatment group. Bleeding rates were similar in both groups. Incidence of documented bradycardia was higher in the AAD group (3 [8.6%] of 35 patients vs. none in the PVI group). Asymptomatic moderate (50%–70%) pulmonary vein (PV) stenosis was documented in 1 (3%) of 32 patients in the PVI group, affecting only one vein; no patient developed severe (>70%) PV stenosis.

In one study,226 there were no serious adverse events in the PVI arm. Significant adverse events leading to permanent drug withdrawal occurred in 23 patients. Proarrhythmia developed in 3 patients in the flecainide group (hypotensive wide QRS tachycardia in 2 patients and 1:1 atrial flutter in 1); thyroid dysfunction occurred in 7 patients in the amiodarone group requiring drug discontinuation; and sexual impairment in 11 patients in the sotalol group.

In one study,225 there were no complications in either group.

In one study,232 3 (4.4%) major complications were related to ablation: one patient had a stroke during left atrium ablation and died 9 months later of brain hemorrhage; another suffered transient phrenic paralysis; and a third had a pericardial effusion which required pericardiocentesis. There was no PV stenosis reported. In the AAD arm, one patient had a TIA, two patients had cancer (one died), and one patient died suddenly.

In one study,253 a total of 155 ablation procedures were performed. Two episodes of cardiac tamponade requiring pericardiocentesis and two groin hematomas were reported; one in each group (one crossover patient), with a favorable outcome in all. A stenosis of the left superior PV that required dilatation and stent implantation occurred in one crossover patient, with an uneventful course thereafter. One case of hyperthyroidism was observed in the AAD group, as well as two deaths that were not deemed related to AADs (acute myeloid leukemia and myocardial infarction).

In one study,222 no serious procedure-related complications were observed except for an access site hematoma severe enough to require a prolongation of hospitalization, which did not require blood transfusion and resolved without any sequelae. Six patients in the AAD group (17.1%) developed significant drug adverse effects. Symptomatic bradycardia requiring a dosage reduction or a change to an alternative drug occurred in five patients, all known to have hypertension. One of the patients underwent implantation of a dual-chamber pacemaker for symptomatic sinus nodal dysfunction. Another patient developed 1:1 atrial flutter while on flecainide.

In one study,228 within 30 days following the intervention, major treatment-related adverse events occurred in 5 patients (1 pericardial effusion, 1 pulmonary edema, 1 pneumonia, 1 vascular complication, and 1 heart failure) in the catheter ablation group (5/103 [4.9%]) and 5 patients (2 with life-threatening arrhythmias and 3 with disabling drug intolerance requiring discontinuation) in the AAD group (5/57 [8.8%]). One patient in the catheter ablation group who had undergone PV isolation alone died 284 days after the procedure due to acute myocardial infarction deemed unrelated to the procedure.

##### Transcatheter PVI Using Different Types of Ablation Catheters

###### Overview

Although we identified three studies comparing types of catheter, these were deemed inappropriate for a meta-analysis given that each study compared different types of catheter, making heterogeneity insurmountable. One study217 compared an 8 mm tip catheter with a cooled tip catheter. A second study210 compared a multipolar circular ablation catheter with point-by-point PVI using an irrigated-tip ablation catheter. One study207 compared a new circular ablation catheter with point-by-point conventional ablation catheter. Results for outcomes of interest are accordingly described qualitatively below.

###### Maintenance of Sinus Rhythm (SR)

One study217 showed that within 6 months and on no AADs, 25 out of 42 patients in the 8 mm tip catheter arm maintained SR versus 20 out of 40 patients in the cooled tip catheter arm (p=0.321). In another study210 and within 6 months, 87.2 percent of patients in whom a multiple circular ablation catheter was used maintained SR compared with 81.5 percent of patients in whom point-by-point PVI with an irrigated tip ablation catheter was used. In another study,207 SR was maintained by 72 percent of patients in the circular ablation catheter arm versus 68 percent of patients in the point-by-point conventional ablation catheter arm (p=0.48) (low strength of evidence).

###### Recurrence of AF

For one study,210 during a mean of 221 days, 12 of 51 patients in whom a multipolar circular ablation catheter was used had recurrent AF versus 15 of 51 patients in whom point-by-point PVI with an irrigated tip ablation catheter was used (p=0.8; low strength of evidence).

###### Stroke

Within 6 months of followup, one study217 reported that the stroke risk was 0 in the 8 mm tip catheter arm versus 1 out of 40 in the cooled tip catheter arm (insufficient strength of evidence).

###### Other Outcomes

None of the studies examined restoration of SR, all-cause or cardiovascular mortality, CV hospitalizations, heart failure symptoms, control of AF symptoms, quality of life, mixed embolic events including stroke, or bleeding events.

###### Adverse Events

In one study,207 no major intraprocedural complications occurred. One patient in the circular ablation catheter group had transient asymptomatic ST-segment elevation in the inferior leads, which was completely reversible within 5 minutes and probably due to air embolism. In the point-by-point conventional ablation catheter group, one patient developed a femoral hematoma, which prolonged hospital stay but did not require surgical revision. Another patient had a deep venous femoral thrombosis without sequelae on followup.

In one study,217 two serious adverse events were observed. One patient randomized to the cooled tip catheter developed transient left-sided weakness 45 minutes after completion of the ablation procedure. CT scan was suggestive of a small right subcortical thromboembolic stroke, and the weakness recovered completely within 24 hours without any intervention. One patient randomized to 8-mm tip catheter developed an LA esophageal fistula that resulted in death.

In one study,210 no serious adverse events were noted in either study group.

##### Transcatheter Circumferential PVI Versus Transcatheter Segmental PVI

###### Overview

We identified 5 RCTs on circumferential vs. segmental PVI,215,221,264-266,275 and the available data were deemed appropriate for a meta-analysis for the maintenance of sinus rhythm. Results for other outcomes are described qualitatively below.

###### Restoration of SR

One study examined restoration of SR immediately post-ablation.266 Not counting the effect of ibutilide and/or cardioversion, SR was restored in 11 out of 40 patients who underwent circumferential PVI versus 7 out of 40 patients who underwent segmental PVI (p=0.40) (insufficient strength of evidence).

###### Maintenance of Sinus Rhythm

A meta-analysis of 5 studies221,264-266,275 included 500 patients and estimated an OR of 1.31 (95% CI, 0.59 to 2.93; Figure 13), demonstrating a potential benefit of circumferential PVI compared with segmental PVI which did not reach statistical significance (low strength of evidence). There was significant heterogeneity. The Q-value was 17.29 for 4 degrees of freedom, p=0.002. Given the wide confidence interval, the heterogeneity, and the fact that this finding did not reach statistical significance, this conclusion should be viewed with caution. The study by Karch and colleagues,275 which appears inconsistent with the other studies, was a fair-quality study from a single center and had a shorter duration of followup (6 months) than the other included studies, which ranged from 9–48 months of followup, and therefore was not necessarily comparable.

Figure 13 Forest plot of maintenance of sinus rhythm for circumferential transcatheter PVI versus segmental transcatheter PVI

Abbreviations: CI=confidence interval; PVI=pulmonary vein isolation

This figure displays a forest plot of five studies that looked at maintenance of sinus rhythm in patients undergoing circumferential PVI compared with segmental PVI. The summary odds ratio was 1.313 (95% CI, 0.588 to 2.932), demonstrating a potential benefit of circumferential PVI compared with segmental PVI which did not reach statistical significance.

###### All-Cause Mortality

One study221 reported that after a mean followup of 48 months, no death occurred in either arm (low strength of evidence).

###### Other Outcomes

None of the studies reported on cardiovascular mortality, CV hospitalizations, heart failure symptoms, control of AF symptoms, quality of life, stroke, mixed embolic events including stroke, or bleeding events.

###### Adverse Events

In one study,275 the composite outcome of periprocedural pericardial tamponade, thromboembolic complications, and PV stenosis was encountered in 6 patients (12%) in the circumferential PV ablation group and in 7 patients (14%) in the segmental PV ablation group (p=0.77). Mild pericardial effusion (3 to 8 mm) was observed in 22 patients in the circumferential PV ablation group versus 5 patients in the segmental PV ablation group (p<0.01). This did not lead to cardiac tamponade in any of the patients, and percutaneous drainage was never needed. Thromboembolic complications occurred as transient ischemic attacks in 2 patients after circumferential PV ablation and in 1 patient after segmental PV ablation. One stroke with a persistent sensorimotor defect was noted in a patient after circumferential PV ablation. PV stenosis occurred after both ablation strategies. However, it was more frequent after segmental PV ablation (6 patients with 7 affected PVs versus 3 patients with 3 affected PVs after circumferential PV ablation). None of the patients with PV stenosis was symptomatic during followup.

In one study,266 no complication occurred in either arm.

In one study,264 three patients from the segmental PVI group and four from the circumferential PVI group developed subcutaneous hematoma and one patient from the segmental PVI group required a blood transfusion. Asymptomatic right superior PV stenosis was detected in one patient in each arm.

In 1 study,265 4 patients in 173 procedures had a systemic embolic event (2.3%), all within the first 2 days after ablation. Of these patients, one stroke and one episode of transient cerebral ischemia occurred in each group. Five patients complained of respiratory symptoms after ablation. All had a normal magnetic resonance angiography, except in 1 patient, with a narrowing of the left inferior PV (30%) with no hemodynamic significance approximately 3 months after the procedure.

In one study,221 there were no atrial esophageal fistulae, embolic complications, or significant pericardial effusion (>5 mm) associated with the first ablation procedure. One patient had a femoral arterial pseudoaneurysm which was cured by pressure. No clinically significant PV stenosis occurred.

##### Transcatheter PVI With Cavotricuspid Isthmus (CTI) Ablation Versus Transcatheter PVI Without CTI Ablation

###### Overview

Because we identified only two studies of transcatheter PVI with CTI ablation versus without CTI ablation,227,272 the data were deemed inappropriate for meta-analysis. Results for outcomes of interest are accordingly described qualitatively below.

###### Recurrence of AF

Two studies reported AF recurrence.227,272 In one study,272 during 2 months of followup AF recurred in 32.6 percent of patients who underwent PVI with CTI compared with 30.5 percent of patients who underwent PVI without CTI (p=NS). In another study,227 AF recurred in 31 percent of patients who had PVI with CTI compared with 24 percent of patients who had PVI without CTI versus (p=0.07) (insufficient strength of evidence).

###### Other Outcomes

None of the studies reported on restoration of SR, maintenance of SR, all-cause or cardiovascular mortality, CV hospitalizations, heart failure symptoms, control of AF symptoms, stroke, mixed embolic events including stroke, quality of life, or bleeding events.

###### Adverse Events

In one study,227 no adverse events were reported. In the second study,272 none of the patients had thromboembolic complications. There was no occurrence of severe PV stenosis (>70%). One patient in each group had moderate (50% to 70%) asymptomatic PV stenosis.

##### Transcatheter PVI With CFAE Ablation Versus Transcatheter PVI Without CFAE Ablation

###### Overview

We identified nine studies on transcatheter PVI with CFAE ablation versus without CFAE ablation,213,215,216,220,223,236,246,267,276 and the available data were deemed appropriate for a meta-analysis for the maintenance of sinus rhythm. Results for other outcomes are described qualitatively below.

###### Restoration of SR

One study reported on restoration of SR immediately after the ablation procedure.220 SR was restored in 13 percent of patients when a circumferential PVI using a 3.5 mm tip irrigated catheter versus 44 percent of patients who underwent PVAI using an open irrigation catheter versus 74 percent of patients in whom CFAE and PVAI were performed. Another study215 demonstrated 65 percent of patients being restored to SR with CFAE while 60 percent was seen in the non-CFAE group (low strength of evidence).

###### Maintenance of Sinus Rhythm

A meta-analysis of 9 studies213,215,216,220,223,236,246,267,276 included 817 patients and estimated an OR of 1.48 (95% CI, 0.74 to 2.98); although there is a potential benefit of CFAE ablation, this finding did not reach statistical significance (Figure 14). We concluded that CFAE ablation in addition to PVI did not increase maintenance of sinus rhythm compared with PVI only (low strength of evidence). There was significant heterogeneity, reducing our confidence in this finding and the strength of evidence rating. The Q-value was 34.06 for 8 degrees of freedom, p<0.001.

Figure 14 Forest plot of maintenance of sinus rhythm for transcatheter PVI with or without CFAE ablation

Abbreviations: CFAE=complex fractionated atrial electrogram; CI=confidence interval; PVI=pulmonary vein isolation

This figure displays a forest plot of nine studies that looked at maintenance of sinus rhythm of patients undergoing transcatheter PVI with or without CFAE ablation. The summary odds ratio was 1.483 (95% CI, 0.737 to 2.984), demonstrating that there was not a statistically significant impact of CFAE ablation on maintenance of sinus rhythm.

###### Quality of Life/Functional Status/Control of AF Symptoms

In one study223 and during 6 months of followup, there was no significant difference in 8 quality-of-life and functional status parameters between the 2 arms of the study (insufficient strength of evidence).

###### Stroke

During a mean followup of 16 months, 1 study220 showed no stroke in the circumferential PVI with a 3.5 mm tip irrigated catheter arm, the PVAI with an open irrigation catheter arm, or the CFAE and PVAI arm (low strength of evidence).

###### Composite Outcomes

One study213 reported on the composite outcome of mixed embolic events including stroke, PV stenosis, and other procedural complications. It showed no significant difference in this outcome between the 2 arms (1 out of 48 patients who underwent PVI vs. 1 out of 50 patients who underwent PVI with CFAE ablation).

###### Other Outcomes

None of the studies reported on all-cause or cardiovascular mortality, CV hospitalizations, heart failure symptoms, or bleeding events. One study216 reported on mixed embolic events including stroke, but it did not specify the arm(s) in which these events occurred.

###### Adverse Events

In one study,216 serious adverse events were observed in 7 patients (5%) and were distributed across the 3 study arms (2% in Arm1, 4% in Arm 2 and 8% in Arm 3, p=0.304). These included groin access complications in three patients (pseudo-aneurysm in one, arterio-venous fistula in one, and large hematoma in one), cerebrovascular events in two patients (transient ischemic attack in one and left cortical micro-embolic stroke in one), pericardial tamponade in one patient and significant PV stenosis requiring stenting.

In one study,213 one pericardial effusion requiring pericardiocentesis occurred in the PVI + CFAE group. A patient in the PVI +CFAE group experienced a prolonged asystole during removal of the venous sheaths 3 hours after the procedure requiring temporary cardiopulmonary resuscitation. Asymptomatic PV stenosis <50 percent (left inferior PV) was detected in 1 patient of the PVI group on the followup MRI scan.

In one study,215 no major complications occurred in either arm.

In 1 study,246 major adverse events were observed in 4 patients (3.4%): 1 patient developed cardiac perforation with cardiac tamponade during the procedure; 1 patient had massive pericardial effusion after the procedure requiring pericardiocentesis; and 2 patients had hemothorax resulting in chest tube insertion. Two patients developed pseudoaneurysms that were managed conservatively. There was no occurrence of significant PV stenosis, system thromboembolism, atrial esophageal fistula, or death.

In one study,236 adverse events occurred in eight patients overall including both initial and repeat procedures. Two cardiac perforations occurred, resulting in cardiac tamponade. Four patients had minor bleeding related to the procedure (three femoral hematomas and one hematuria from urinary catheter insertion), none requiring transfusion or intervention. One patient had a vascular complication (pseudoaneurysm) that was managed with local injection, and 1 patient had minor (30%) PV stenosis of one vein (left inferior). There were no occurrences of significant PV stenosis, embolic complication, stroke, atrial-esophageal fistula, or death.

In one study,223 one of the patients randomly assigned to PVAI had an intraprocedural pericardial effusion that was drained in the electrophysiology laboratory. No patient had PV stenosis in excess of 20 percent. There were no thromboembolic events or strokes. One of the patients was started on amiodarone after an early recurrence and continued it until 9 months after ablation. Although this patient had no further AF recurrences during this period, the outcome was classified as ablation failure, based on study definitions.

In one study,220 two pericardial effusions were seen in group 3; one was treated with percutaneous drainage, and the other one required surgical drainage. Two patients had asymptomatic PV stenosis on the computed tomography scan assessment after ablation that remained stable over time (1 patient from group 3, 30% to 40% in the left inferior PV [LIPV], and 1 patient from group 2, 40% in the right inferior PV [RIPV]). No esophageal fistulae or strokes occurred.

In 1 study that involved 157 ablation procedures performed on 119 patients,276 2 patients developed transient pericarditis, and 1 patient had a small pericardial effusion without tamponade. Two vascular complications occurred, including a self-limited extraperitoneal bleed and a femoral arteriovenous fistula.

##### Transcatheter PVI Versus Transcatheter PVI With Ablation Sites Other Than CTI and CFAE and Transcatheter PVI Involving all Four PVs Versus Transcatheter PVI Involving Arrhythmogenic PVs only

###### Overview

Although we identified 19 studies examining ablation sites other than CTI and CFAE,211,218,233,238,239,244,247,250-252,255,257,271,277-280,282,283 these were deemed inappropriate for a meta-analysis because each study compared different ablation site(s). One study specifically focused on transcatheter PVI involving arrhythmogenic PVs only.294 Results for outcomes of interest are accordingly described qualitatively below.

###### Restoration of SR

Restoration of SR was only reported by two studies.238,277 One238 showed restoration of sinus rhythm in 79.9 percent of the left atrial group patients and 76 percent restoration in the biatrial group of patients (p=0.49). In another study277 of 85 patients undergoing ablation, AF converted to sinus rhythm in 8 (9%) and to atrial tachycardia/flutter in 11 (13%) during left atrial ablation (insufficient strength of evidence).

###### Maintenance of SR

Fifteen studies reported on maintenance of SR.218,233,238,244,247,250-252,255,257,271,277,279,280,282 In four studies,244,250,251,280 maintenance of SR was significantly higher in the group that underwent additional ablation sites to PVI. In one study,247 superior vena cava isolation in addition to PVI improved maintenance of SR only in patients with paroxysmal AF. In one study,218 isolation of the arrhythmogenic veins was as efficacious as empiric isolation of all veins in achieving long-term control of AF. In nine studies,233,238,252,255,257,271,277,279,282 additional ablation sites to PVI did not enhance maintenance of SR (insufficient strength of evidence).

###### Recurrence of AF

Although 6 studies involving 572 patients evaluated recurrence of AF, the findings were inconsistent and imprecise, resulting in an insufficient strength of evidence rating.

Specifically, in one study,211 during a mean followup of 14 months, AF recurred in 39 percent of patients in the left atrial ablation group and in 15 percent of patients in the biatrial ablation group (p=0.022).

In another study257 and during a mean followup of 23 months, AF recurrence was not significantly different between the PVI only group and the PVI with additional ablation sites group.

In a third study,239 AF recurrence was significantly lower in the PVI + substrate modification consisting of a roofline connecting both left superior and right superior PV and LA isthmus ablation between left inferior PV and mitral annulus than in the PVI only group (44% vs. 77% within 1 month, p=0.002 and 31% vs. 80% within 12 months, p=0.0001).

In another (poor-quality) study,283 after the initial ablation procedure, there was no statistically significant difference in AF recurrence between the two groups of PVI vs. PVI and superior vena cava isolation.

In another study,278 the early AF recurrence rate within 3 months of the procedure was not significantly different among patients randomized to PVI vs. PVI + left atrial roof line ablation vs. PVI + left atrial roof line ablation + linear ablation at the posterior inferior left atrial wall (p=0.384).

One study279 showed that after a mean followup period of about 16 months and after 1 ablation procedure, 19 (58%) patients in the segmental PVI group were free of atrial arrhythmias off all antiarrhythmic therapy, as compared with 17 (52%) patients in the PVI and left atrial linear ablation group (p=0.62; insufficient strength of evidence).

###### All-Cause Mortality

In one study218 and within 1 year of followup, 1 out of 53 patients in the all PVI group died compared with 0 out of 52 patients in the selected (arrhythmogenic) PVI group. In another study,238 the 4-year actuarial survival was 98.7±1.1 percent in the biatrial group and 100 percent in the left atrial group (p=0.50) (insufficient strength of evidence).

###### Quality of Life/Functional Status/Control of AF Symptoms

In one study,255 there was no significant difference in the control of AF symptoms between the single PVI vs. all PVI group. In another study271 and within 9 months of followup, there was no significant difference in the control of AF symptoms between the PVI group and the PVI + two linear lesions (one between the superior PVs and one from the left inferior PV to the mitral valve annulus) (low strength of evidence).

###### Stroke

In one study,238 the 1- and 3-year actuarial survival free from stroke rates were both 100 percent in the left atrial group, and 98.7±3.5 percent and 93.6±5.7 percent in the biatrial group, respectively (p=0.50).

In another study,239 1 out of 32 patients had a stroke in the PVI + substrate modification vs. 0 of 30 patients in the PVI group (insufficient strength of evidence).

###### Other Outcomes

None of the studies reported on cardiovascular mortality, CV hospitalizations, heart failure symptoms, mixed embolic events including stroke, bleeding events, or other adverse events.

##### Transcatheter PVI Alone Versus Transcatheter PVI Plus Postablation Antiarrhythmic Drugs

###### Overview

Two studies compared PVI alone with PVI plus postablation AADs.229,234 Results for outcomes of interest are described qualitatively below.

###### Recurrence of AF

In one study234 and during 12 months of followup, AF recurred in 18 out of 53 patients who received no AAD postablation compared with 16 out of 54 patients who received an AAD postablation (p=0.63). The other study229 showed that within 6 weeks post-PVI, AF recurred significantly more in the group of patients who received no AAD after ablation than the group of patients who received an AAD after ablation (15/57 vs. 2/53, p=0.0012). Given the inconsistency in findings and varying followup times, we determined the strength of evidence to be insufficient.

###### CV Hospitalizations

No study reported generally on CV hospitalizations. One reported specifically on AF hospitalizations.229 This study showed no significant difference between the AAD arm and no AAD arm (low strength of evidence).

###### Composite Outcomes

One study229 examined a composite outcome of (1) atrial arrhythmias lasting >24 hours; (2) atrial arrhythmias associated with severe symptoms requiring hospital admission, cardioversion, or initiation/modification of AAD therapy; and (3) intolerance to antiarrhythmic agent requiring drug cessation or change. Within 6 weeks, the rate of this outcome was significantly lower in the AAD arm than in the no AAD arm (10/53 vs. 24/57, p=0.005).

###### Other Outcomes

Neither study reported on restoration of SR, all-cause or cardiovascular mortality, heart failure symptoms, control of AF symptoms, quality of life, stroke, mixed embolic events including stroke, or bleeding events,.

###### Adverse Events

One study234 did not report any adverse events. In the second study229 three patients in the AAD group experienced side effects, presumably related to the antiarrhythmic agent, requiring drug cessation. These side effects consisted of a skin rash, severe fatigue, and recurrent severe headaches.

##### Surgical Maze Versus Standard of Care (Mitral Valve Surgery)

###### Overview

We identified eight RCTs for this comparison,214,231,240,242,243,248,254,263 and the available data were deemed appropriate for a meta-analysis for the following outcomes: maintenance of sinus rhythm and all-cause mortality. Results for other outcomes are described qualitatively below.

###### Maintenance of Sinus Rhythm

Seven studies evaluated maintenance of sinus rhythm in patients undergoing surgical Maze versus standard of care (specifically mitral valve surgery).214,240,242,243,248,254,263 A meta-analysis of these 7 studies included 361 patients and estimated an OR of 5.80 (95% CI, 1.79 to 18.81), demonstrating a large and statistically significant benefit of the Maze procedure compared with mitral valve surgery for maintenance of sinus rhythm (Figure 15; moderate strength of evidence). There was significant heterogeneity, which—despite the large estimated benefit—reduced our strength of evidence rating. The Q-value was 23.15 for 6 degrees of freedom, p=0.001. Although the two outlier studies243,248 were both fair-quality studies where the randomization and reason for exclusion of specific patients from either randomization or analysis were unclear, the other five studies were also variable in quality (four fair- and one good-quality study) with small samples, and unclear methods.

Figure 15 Forest plot of maintenance of sinus rhythm for Maze procedure versus standard of care (mitral valve surgery)

Abbreviation: CI=confidence interval

This figure displays a forest plot of seven studies that looked at maintenance of sinus rhythm in patients undergoing surgical Maze versus standard of care or rhythm control using antiarrhythmic drugs. The summary odds ratio was 5.805 (95% CI,1.791 to 18.812), demonstrating a large and statistically significant benefit of the Maze procedure for this outcome.

###### All-Cause Mortality

Six studies evaluated all-cause mortality in patients undergoing surgical Maze versus standard of care (mitral valve surgery).214,231,240,242,243,248 A meta-analysis of these 6 studies included 387 patients and estimated an OR of 1.97 (95% CI, 0.81 to 4.80), demonstrating a potential increase in mortality associated with the Maze procedure compared with mitral valve surgery, although this finding did not reach statistical significance (Figure 16; low strength of evidence). There was no evidence of heterogeneity. The Q-value was 2.24 for 5 degrees of freedom, p=0.815. Note that the study by Akpinar and colleagues242 was performed in Turkey and involved a small number of deaths, several of which were, according to the study authors, unrelated to the procedure or cardiovascular in nature (e.g., long-standing pulmonary infection, traffic accident).

Figure 16 Forest plot of all-cause mortality for Maze procedure versus standard of care (mitral valve surgery)

Abbreviation: CI=confidence interval

This figure displays a forest plot of six studies that looked at all-cause mortality in patients undergoing surgical Maze versus standard of care or rhythm control using antiarrhythmic drugs. The summary odds ratio was 1.965 (95% CI, 0.805 to 4.796), demonstrating a potential increase in mortality associated with the Maze procedure compared with other strategies, although this finding did not reach statistical significance.

Reviewing the timing of mortality within the Maze groups for the included studies, the mortality in one study240 occurred from septic shock after pneumonia 17 days postprocedure; none of the deaths in another study242 were considered related to the procedure; in a third study,243 1 death in the Maze group was immediate and caused by tamponade/reoperation, and 2 additional deaths occurred 57 days and 20 months postprocedure and were caused by acute renal failure/septic shock and coronary artery dissection during catheterization, respectively. In another study,248 there was 1 hospital death on the 57^th^ postoperative day, caused by sepsis, in a patient who underwent the Maze procedure. In another study,214 1 patient within the Maze group died after 40 days due to renal bleeding under standard anticoagulation as performed after prosthetic mitral valve implantation (INR 2·5 to 3·5). One patient died after 45 days from mediastinitis; 1 sudden cardiac death occurred after 4 months; and 1 death due to respiratory insufficiency followed severe lung fibrosis after 7 months. As detailed, many of these deaths in the Maze arm were most likely not related to the procedure itself.

###### Heart Failure Symptoms

In one study214 and during 6 months of followup, there was no significant difference in heart failure symptoms between patients who underwent the Maze procedure in conjunction with mitral valve replacement and those who did not undergo the Maze procedure in conjunction with mitral valve replacement (2.5/15 vs. 2.6/15, p=0.531) (insufficient strength of evidence).

###### Stroke

One study248 examined stroke in the immediate postoperative period. It found that the rate of stoke was 0, 0, and 1 out of 10 in the PVI+mitral valve correction group, the surgical Maze plus mitral valve correction group, and mitral valve correction only group, respectively (insufficient strength of evidence).

###### Mixed Embolic Events Including Stroke

In one study242 and within 1 year of followup, the risk of mixed embolic events including stroke was 0 in the mitral valve surgery plus Maze group vs. 6 percent in the mitral valve surgery only group (p=0.08) (insufficient strength of evidence).

###### Bleeding Events

One study243 reported on hemorrhagic stroke. It found that during a mean followup of 35 months, this outcome occurred in 2 out of 20 patients who underwent surgical PVI versus 1 out of 20 in patients who underwent the surgical Maze versus 0 out of 20 in the control group who underwent mitral valve correction only. Patients in the control group but not in other groups also had other causes of bleeding: epistaxis (n=2), petechiae (n=1), hematuria (n=1) and lower GI bleeding (n=1) (insufficient strength of evidence).

###### Other Outcomes

None of these studies reported on cardiovascular mortality or CV hospitalizations.

###### Adverse Events

In 1 study,214 1 patient from the surgical Maze died after 40 days due to renal bleeding under standard anticoagulation as performed after prosthetic mitral valve implantation (INR 2·5 to 3·5).

In 1 study,242 1 (3%) patient in the Maze group required a pacemaker vs. 0 in the mitral valve surgery only group (p>0.05). One patient (3%) in the Maze group and 1 patient in the valve surgery only group (2.9%) required reoperation for bleeding (p>0.05). Prolonged ventilation occurred in 1 patient in the Maze group vs. 0 patients in the valve surgery only group (p>0.05). Late tamponade occurred in 1 (3%) patient in the Maze group and in 2 (6%) patients in the valve surgery only group (p>0.05). A thromboembolic event occurred in 0 patients in the Maze group versus 2 patients (6%) in the valve surgery only group (p=0.08).

In one study,254 one patient in the Maze group had an intraoperative MI, and one patient in the control group had a stroke.

In another study,248 there was 1 hospital death on the 57^th^ postoperative day, caused by sepsis, in a patient who underwent the Maze procedure. One redo surgical intervention was necessary because of bleeding and hemopericardium in a patient in the control group. This patient suffered a stroke and pulmonary embolism, but exhibited a favorable clinical outcome. Four patients had previous history of stroke but only one had cerebral ischemia during the postoperative period. No patient required a permanent pacemaker during followup. There was one case of intestinal bleeding (not clear in which group), during the second postoperative week, which required surgical intervention. There were no other major complications.

In 1 study,240 the in-hospital mortality rate was 0 in the mitral valve surgery only group and 2.3 percent in the Maze group (p>0.99). One patient in the Maze group died of septic shock after pneumonia on the 17^th^ postoperative day. One patient (2.3%) in the Maze group and 1 patient (3.5%) in the mitral valve surgery only group received a permanent pacemaker because of symptomatic bradyarrythmia. Endocarditis occurred in one patient (3.5%) in the mitral valve surgery only group versus zero in the Maze group. Pneumonia occurred in 3 (7.1%) patients in the Maze group versus 1 (3.5%) in the mitral valve surgery only group, and mediastinitis occurred in 1 (2.3%) patient in the Maze group versus 0 patients in the mitral valve surgery only group.

In one study,243 two hemorrhagic strokes occurred in the surgical PVI group versus one in the Maze group versus zero in the control group. One patient in the surgical PVI group had perioperative MI. One patient in the Maze group had mediastinitis, and one patient in the Maze group had immediate reoperation for bleeding. One patient in the control group had a TIA, and four patients in the control group had bleeding.

In 1 study,263 1 patient who had circumferential PVI 6 months after valve surgery developed major stroke with right-sided hemiplegia during the procedure. There were no femoral vein access site complication and cardiac tamponade in either group, and there was no PV stenosis during followup. One patient in the Maze procedure group (done concomitantly with valve surgery) had pericardial effusion 5 days after the operation and it disappeared 15 days after the procedure. Sternal wound infection was found in three patients in the circumferential PVI group and four patients in the Maze group, and was treated with intravenous antibiotics. Pneumonia occurred in four cases in the circumferential PVI group and three cases in the Maze group and recovered in all cases. There was no significant difference in the rates of complications between the two groups (p>0.05).

In one study,231 two deaths were recorded in the biatrial and PVI Maze groups with no mortality in the other two groups (left atrial Maze and valve surgery only groups). Five patients required reexploration for bleeding, two each in the valve surgery only group and left atrial Maze group, and one patient in the biatrial Maze group. Three patients who underwent biatrial Maze, two patients in the left atrial Maze group and one patient in the valve surgery only group required a prolonged hospital stay for low cardiac output. One patient in the PVI Maze group developed mediastinitis.

##### PVI at the Time of Cardiac Surgery Versus Cardiac Surgery Alone or in Combination With Antiarrhythmic Drugs or Catheter Ablation

###### Overview

We identified 9 RCTs for this comparison,208,209,212,219,235,237,268,270,274 and the available data were deemed appropriate for a meta-analysis for restoration and maintenance of sinus rhythm. Results for other outcomes are described qualitatively below.

###### Restoration of Sinus Rhythm

Four studies evaluated restoration of sinus rhythm.212,219,237,268 Three of were combined in a meta-analysis.212,219,237 In the fourth study,268 all patients in both arms remained in sinus rhythm during the immediate postprocedure period; because of the lack of events, this study could not be combined quantitatively with the others. The 3 included studies involved 181 patients and estimated an OR of 12.30 (95% CI, 1.31 to 115.29), demonstrating a statistically significant benefit of PVI at the time of cardiac surgery for restoration of sinus rhythm (Figure 17; high strength of evidence). There was significant heterogeneity. The Q-value was 10.95 for 2 degrees of freedom, p=0.004. Despite the heterogeneity, the overall benefit of PVI was consistent across the studies and allowed us to assign a high strength of evidence rating.

Figure 17 Forest plot of restoration of sinus rhythm for PVI at the time of cardiac surgery versus cardiac surgery alone or in combination with antiarrhythmic drugs or catheter ablation

Abbreviation: CI=confidence interval; PVI=pulmonary vein isolation

This figure displays a forest plot of three studies that looked at restoration of sinus rhythm of patients undergoing PVI at the time of cardiac surgery with cardiac surgery only or in combination with antiarrhythmic drugs or catheter ablation. The summary odds ratio was 12.303 (95% CI, 1.313 to 115.289), demonstrating a statistically significant benefit of PVI at the time of cardiac surgery for this outcome.

###### Maintenance of Sinus Rhythm

Eight studies evaluated maintenance of sinus rhythm.208,209,212,219,235,268,270,274 Meta-analysis of these 8 studies included 532 patients and estimated an OR of 3.91 (95% CI, 1.54 to 9.91), demonstrating a statistically significant benefit of PVI at the time of cardiac surgery for maintenance of sinus rhythm (Figure 18; high strength of evidence). There was significant heterogeneity. The Q-value was 29.02 for 7 degrees of freedom, p<0.001. Note that the Pires study268 compared surgical cut and sew versus PVI and, as such, was quite different from the other included studies. Eliminating this study from our meta-analysis did not substantially change our findings and therefore allowed us to maintain the high strength of evidence rating.

Figure 18 Forest plot of maintenance of sinus rhythm for PVI at the time of cardiac surgery versus cardiac surgery alone or in combination with antiarrhythmic drugs or catheter ablation

Abbreviations: CI=confidence interval; PVI=pulmonary vein isolation

This figure displays a forest plot of eight studies that looked at restoration of sinus rhythm of patients undergoing PVI at the time of cardiac surgery versus cardiac surgery only or in combination with AAD or catheter ablation. The summary odds ratio was 3.910 (95% CI, 1.542 to 9.911), demonstrating a statistically significant benefit of PVI at the time of cardiac surgery for this outcome.

###### All-Cause Mortality

In one study212 and during 12 months of followup, 1 out of 22 patients in the ablation arm and 0 out of 22 patients in the control arm (p=NR) died. In another study,274 within 1 year, 3 out of 22 patients died in the ablation arm versus 1 out of 21 in the control arm (p=NR) (low strength of evidence).

###### Cardiovascular Mortality

In one study,219 cardiovascular mortality in the immediate postoperative period was experienced by 3 out of 45 patients in the ablation arm and 4 out of 44 patients in the control arm (p=NR) (insufficient strength of evidence).

###### Quality of Life/Functional Status/Control of AF Symptoms

In one study,219 functional status was assessed by the shuttle-walk test. No significant differences in this test were found between the ablation group and the control group at 6 months; however, the distance covered at 12 months was significantly longer in the ablation group than in the control group (359 meters vs. 304 meters, p=0.02).

In one study,235 cardiac surgery in general resulted in an overall improvement of the RAND SF-36 and the MFI-20. However, the EQ-5D showed a significant deterioration in the subscale Pain/Discomfort for both groups (p<0.001), with a significantly worse outcome for the control group (p=0.006). The authors concluded that health-related quality of life in patients with paroxysmal, permanent, and persistent AF improves after cardiac surgery, but this improvement is presumably more affected by treating the underlying heart disease than by restoring sinus rhythm (insufficient strength of evidence).

###### Stroke

In one study,219 the risk of stroke within 12 months of followup was not significantly different between the PVI group and the control group. In another study,212 the rate of stroke within 12 months of followup was 3 out of 21 in the PVI group vs. 0 out of 22 in the control group (p=NR) There was low strength of evidence that there is no difference between PVI and control groups..

###### Bleeding Events

In one study,212 significant postoperative bleeding occurred in 1 out of 21 patients in the ablation arm and 3 out of 22 patients in the control arm (p=NR) (insufficient strength of evidence).

###### Composite Outcomes

One study212 reported on the composite outcome of recurrence of AF, all-cause mortality, stroke, and postprocedure complications within 1 year of followup. This outcome occurred in 16 out of 21 patients in the ablation arm versus 11 out of 22 patients in the control arm (p=0.14).

###### Other Outcomes

None of these studies reported on CV hospitalizations, heart failure symptoms, or mixed embolic events including stroke.

###### Adverse Events

In one study209 the procedural adverse event rate was significantly higher for minimally invasive surgical ablation with 23.0 percent (14 serious adverse events [SAEs] in 14 patients) than for catheter ablation with 3.2 percent (2 SAEs in 2 patients; p=0.001). One patient in each group had a procedure-related stroke, and one patient in each group had a TIA. In the surgical ablation group, six patients had pneumothorax, one patient had hemothorax, one patient had rib fracture, one patient needed sternotomy for access to control bleeding, one patient had pneumonia, and two patients required a permanent pacemaker.

In another study,270 two in-hospital deaths occurred. One patient (ablation group) died at postoperative day 19 due to cerebral air embolism of unknown origin. A thorough autopsy did not reveal any link to the previously performed microwave ablation therapy. The second patient (control) died because of refractory heart failure.

In 1 study,219 operative mortality was 6.1 percent in the ablation group vs. 8.3 percent in the mitral valve surgery only group. Stroke or TIA occurred in 4 percent of patients in the ablation group and 2.1 percent of patients in the mitral valve surgery only group. Sepsis occurred in 6.1 percent of patients in the ablation group vs. 4.2 percent in the mitral valve surgery only group.

In 1 study,208 the rate of in-hospital complications, excluding pacemaker implantations, was 11.4 percent (4 patients) in the mitral valve surgery group and 26.5 percent (9 patients) in the cryoablation group (p=0.110). Low cardiac output syndrome occurred while weaning from bypass in three patients, it was related to right heart failure and preoperative myocardial infarction in two patients, respectively, and required temporary assist by intra-aortic balloon pump in three patients. All except one patient, who died on the third postoperative day, recovered. The in-hospital mortality rate was 2.9 percent (1/34 patients) in the cryoablation group and 0 in the mitral valve surgery alone group. The permanent pacemaker implantation rate did not differ between the two treatment groups (p=0.583).

In one study,212 there was one death in the ablation group in a patient who developed postoperative cardiogenic shock rapidly followed by massive ischemic stroke. It was necessary to implant pacemakers in five patients (three patients in the ablation group and two patients in the control group). One patient from each group underwent a second valve replacement. Four patients presented with severe postoperative hemorrhage: one patient in the ablation group and three patients in the control group. Three patients in the ablation group had strokes. One patient had postoperative left hemiplegia due to gas embolism. During the immediate postoperative period, one patient had a TIA. In the control group, one patient presented with a TIA.

In one study,237 no ablation device-related adverse events were reported. All significant adverse events were classified as “related to cardiac surgery” or to “pre-existing disease.” Notably, there were no peri- or postoperative cerebrovascular accidents in either group.

In one study,274 in the ablation group, no device- or procedure-related complication was observed.

In one study,268 one patient in radiofrequency ablation group developed cardiac tamponade requiring surgical intervention. No patients died.

In one study,235 during the postoperative in-hospital period the number of re-do thoracotomies, pulmonary complications, stroke, myocardial infarction, renal failure, and infection rate showed no significant differences between patient groups. During followup, the total number of adverse events remained equally distributed among both groups. The overall in- and out of hospital mortality rate was 5.3 percent (n=7): 5 patients in the control group versus 2 patients in the surgical ablation group.

### Pharmacological Therapies for Rhythm Control

#### Description of Included Studies

A total of 18 studies including 4,300 patients and published between 2000 and 2010 compared the safety or effectiveness of pharmacological agents with or without external electrical cardioversion for maintaining sinus rhythm in patients with AF. Six studies were of good quality,178,180,181,224,230,256 10 were of fair quality,144,145,241,245,249,258-261,269 and 2 were of poor quality.205,281 Seven studies were multicenter,145,180,224,230,241,249,256 10 were single-center studies,144,178,205,245,258-261,269,281 and in 1 study was undefined.181 One study was conducted entirely in the United States,180 10 were conducted entirely in Europe144,145,178,181,205,245,249,269,281 5 were conducted specifically in Greece,256,258-261 one was conducted completely in Canada,230 and one was conducted on several continents.224 Two studies were funded by government and industry,180,241 one was funded solely by government,230 two were funded by industry and nongovernment sources,145,178 one was funded solely by industry,224 and the funding source was unclear for 12 studies.144,181,205,245,249,256,258-261,269,281 For eight of the studies, the setting was unclear or not reported.145,178,181,224,230,241,245,269 Of the remaining nine studies, four included an inpatient setting,144,205,249,281 six included an outpatient setting,180,256,258-260,281 and four included an emergency room setting.258-261 Four studies included patients with paroxysmal or persistent AF,258-261 and seven studies included patients with persistent AF.144,145,178,249,256,269,281 Sixteen studies including 3,660 patients reported the sex of study participants: 33% were female and 67% were male.144,145,178,180,181,205,224,241,245,249,256,258-261,269

Five studies evaluated the use of one or more pharmacological agent with external electrical cardioversion as a primary component of the tested intervention;144,145,178,205,281 1 study compared an AAD with a rate-controlling drug (sotalol vs. bisoprolol);269 1 study evaluated the effect of the addition of verapamil to either amiodarone or flecainide;249 1 study compared two beta blockers;256 and 10 studies compared two or more AADs.180,181,224,230,241,245,258-261

#### Detailed Synthesis

Studies of pharmacological agents are presented in two groups: (1) those that included the use of electrical cardioversion as a key component of the study protocol (5 studies144,145,178,205,281 and (2) those that compared pharmacological agents as the primary component of the interventions and may have included electrical cardioversion as a minor component (13 studies).180,181,224,230,241,245,249,256,258-261,269

##### Pharmacological Therapy in Which Electrical Cardioversion is a Key Component of the Treatment

Five studies involving 582 patients evaluated pharmacological therapy in which electrical cardioversion was a key component of the treatment.144,145,178,205,281 Four of these included only patients with persistent AF.144,145,178,281 Two studies evaluated the effect of adding a drug (verapamil205 or metoprolol178) to external electrical cardioversion. Two studies compared the use of two different drugs in this context,144,145 one of which also evaluated the use of two electrical cardioversion methods (daily monitoring resulting in acute electrical cardioversions with recurrences vs. routine monitoring potentially resulting in less frequent electrical cardioversions with recurrences).145 One poor-quality study compared a method of giving up to two additional electrical cardioversions versus no additional electrical cardioversions in patients receiving Class Ic or Class III AADs.281

###### Maintenance of Sinus Rhythm

One good-quality study reported maintenance of sinus rhythm at 1.5, 3, and 6 months after electrical cardioversion in patients receiving metoprolol versus placebo.178 A statistically significant greater proportion of patients maintained sinus rhythm in the metoprolol versus placebo group at all time points (1.5 months: 51% vs. 33%, p=0.02; 3 months: 47% vs. 28%, p=0.01; 6 months: 46% vs. 26%, p=0.03). The results were the same for patients who were allowed one additional electrical cardioversion (67% vs. 42% for metoprolol vs. placebo, p=0.02) and for patients who were allowed two additional electrical cardioversions (24% vs. 8%, p=0.03) Lack of studies and small sample size resulted in insufficient strength of evidence for this outcome.

###### Recurrence of AF

Four studies reported recurrence of AF at different time points ranging from 2–18 months.144,145,205,281 One fair-quality study compared use of amiodarone versus diltiazem 2 months after electrical cardioversion and found that 31 percent of amiodarone patients versus 52 percent of diltiazem patients had a recurrence of AF (p<0.01).144 A poor-quality study compared verapamil with no verapamil given for 3 days before and after electrical cardioversion; 3 months after cardioversion; 19 percent of those receiving verapamil versus 39 percent of those not receiving verapamil had a recurrence of AF (p=0.03).205 Antiarrhythmic drugs were used in both study arms at the discretion of the physician and were not accounted for in the analysis. A third, fair-quality study compared the use of digoxin and verapamil with different electrical cardioversion protocols.145 There was no significant difference in recurrence of AF at 18 months between digoxin and verapamil users (36% vs. 28%, respectively; p=0.33). This study also compared the use of acute versus routine subsequent electrical cardioversions regardless of receipt of digoxin or verapamil and found no difference in the proportion of patients with recurrence of AF at 18 months (32% vs. 28 %, p=0.85). A fourth, poor-quality study compared use of two subsequent electrical cardioversions versus none in patients receiving Class Ic or III AADs.281 There was no difference in recurrence of AF from 3 to 12 months after the initial electrical cardioversion between the groups (extra cardioversions allowed 29 percent vs. no extra cardioversions allowed 31 percent, p=0.83) Differences in followup, agents, and findings resulted in an insufficient strength of evidence rating for this outcome.

###### All-Cause Mortality

One good-quality study178 reported that one patient who received metoprolol with electrical cardioversion died within 6 months compared with no patients who received placebo plus electrical cardioversion. No statistical tests were performed (insufficient strength of evidence).

###### Quality of Life

One fair-quality study reported no statistically significant difference in overall quality of life (SF-36) at 18 months in those receiving digoxin versus verapamil or those receiving acute versus routine subsequent electrical cardioversions.145 Scores were not provided, and no p-values were reported for the overall quality-of-life assessment (insufficient strength of evidence).

###### Stroke

One good-quality study reported that one patient receiving metoprolol with electrical cardioversion versus no patients receiving placebo with electrical cardioversion had a stroke178 (insufficient strength of evidence).

###### Results in Specific Subgroups of Interest

No results were reported for outcomes of interest in specific subgroups of interest.

##### Comparison of Pharmacological Agents

Thirteen studies with a total of 3,718 patients compared pharmacological agents (Table 15).180,181,224,230,241,245,249,256,258-261,269 One of these studies compared an AAD with a beta-blocker (sotalol vs. bisoprolol),269 one focused on the effect of the addition of verapamil to both amiodarone and flecainide,249 and one compared two beta-blockers, carvedilol and bisoprolol.256 The remaining 10 studies compared two or more AADs. Five studies included a placebo arm; results of the placebo arm were not included in this review.180,181,245,258,260

Table 15 Studies including comparisons of pharmacological agents

Study | Sample Size (N) | Drug Comparison | Outcomes Assessed
Kochiadakis, 2000^260^ | 186 | Amiodarone vs. Sotalol | Composite (Recurrence of AF or Adverse drug effect): 1 month,12 months, 24 months, mean monthly progression Composite (Maintenance of SR and Free of adverse drug effects): 1 year, 2 years
Kochiadakis, 2000^261^ | 214 | Amiodarone vs. Sotalol vs. Propafenone | Composite (Recurrence of AF or Adverse drug effect): 12 months, 24 months, mean monthly progression Recurrence of AF: 2 years, and monthly rate Composite (Maintenance of SR and Free of adverse drug effects): 1 year, 2 years
Roy, 2000^230^ | 403 | Amiodarone vs. Sotalol/Propafenone | AF hospitalization: 12 months, All-cause mortality: mean Control of AF symptoms: 3 months Recurrence of AF at mean followup of 468 days, and time to event Quality of life Stroke
Bellandi, 2001^245^ | 300 | Sotalol vs. Propafenone | Maintenance of SR: 1 year Recurrence of AF: 12 months, mean time
Plewan, 2001^269^ | 128 | Sotalol vs. Bisoprolol | Maintenance of SR: 12 months Recurrence of AF: 12 months, mean days to recurrence, monthly rate of recurrence
Anonymous, 2003^241^ | 256 | Amiodarone vs. Sotalol | All-cause mortality: 5 years Arrhythmic deaths: 5 years Maintenance of SR: 5years Recurrence (prevalence) of AF: 4 months, 1 year
De Simone, 2003^249^ | 324 | Amiodarone vs. Flecainide vs. Amiodarone with Verapamil vs. Flecainide with Verapamil | AF-free survival at 90 days (amiodarone/flecainide vs. amiodarone/flecainide with verapamil) Recurrence of AF: 3 months Maintenance of SR: 3 months
Katritsis, 2003^256^ | 90 | Carvedilol vs. Bisoprolol | Recurrence of AF: 1 year
Kochiadakis, 2004^258^ | 254 | Sotalol vs. Propafenone | Composite (Recurrence of AF or Adverse drug effect): 12 months, mean monthly progression; Composite (Maintenance of SR and Free of adverse drug effects): 30 months
Kochiadakis, 2004^259^ | 146 | Amiodarone vs. Propafenone | Composite (Recurrence or Adverse drug effect): 12 months, 24 months, mean monthly progression Recurrence of AF Composite (Maintenance of SR and Free of adverse drug effects): 1 year, 2 years
Singh, 2005^180^ | 665 | Amiodarone vs. Sotalol | All-cause mortality at last followup Stroke (per 100 person years) Recurrence of AF: 1 year, median days to recurrence Quality of life
Vijayalakshmi, 2006^181^ | 94 | Amiodarone vs. Sotalol | All-cause mortality: 6 months Maintenance of SR: 1.5 months, 6 months
Le Heuzey, 2010^224^ | 504 | Amiodarone vs. Dronedarone | Composite (Recurrence or Adverse drug effect), time to event Recurrence of AF: 12 months after conversion to SR All-cause mortality

Abbreviations: AF=atrial fibrillation; N=number of participants; SR=sinus rhythm

###### Maintenance of Sinus Rhythm

Nine studies comparing primarily pharmacological interventions reported this outcome.181,241,245,249,258-261,269 Four studies compared amiodarone with sotalol,181,241,260,261 two of which reported a composite outcome of maintenance of sinus rhythm without adverse effects from medication.260,261 In all four studies maintenance of sinus rhythm was greater with amiodarone than with sotalol, but the differences were statistically significant only in some studies and at some of the assessed time points (see Table 16).

Table 16 Studies assessing maintenance of sinus rhythm with or without adverse effects

Study | Sample Size (N) | Time Point | Results | P-Value
Kochiadakis, 2000^261^ | 214 | 1 year^a^ | Amiodarone: 70.9% Sotalol: 39.2% Propafenone: 60.4% | NR
Kochiadakis, 2000^261^ | 214 | 2 years^a^ | Amiodarone: 44.7% Sotalol: 19.6% Propafenone: 60% | NR
Kochiadakis, 2000^260^ | 186 | 1 year^a^ | Amiodarone: 58.46% Sotalol: 36.07% | NR
Kochiadakis, 2000^260^ | 186 | 2 years^a^ | Amiodarone: 26.17% Sotalol: 12.61% | NR
Bellandi, 2001^245^ | 300 | 1 year | Propafenone:56% Sotalol: 61% | 0.51
Plewan, 2001^269^ | 128 | 12 months | Bisoprolol: 55% Sotalol: 52% | NS
Anonymous, 2003^241^ | 256 | 5 years | Amiodarone vs. Sotalol Overall % without recurrences NR for cumulative time period Amiodarone had greater maintenance than Sotalol | p=0.0003
De Simone, 2003^249^ | 324 | 90 days | AF-free survival between Amiodarone/Flecainide vs. Amiodarone/Flecainide + Verapamil HR 2.17 (95% CI, 1.39 to 3.39) | p<0.001
Kochiadakis, 2004^258^ | 254 | 30 months^a^ | Propafenone: 47% Sotalol: 25% | NR
Kochiadakis, 2004^259^ | 146 | 12 months^a^ | Amiodarone: 72% Propafenone: 56% | NR
Kochiadakis, 2004^259^ | 146 | 24 months^a^ | Amiodarone: 42% Propafenone: 51% | NR
Vijayalakshmi, 2006^181^ | 94 | 1.5 months | Amiodarone: 67% Sotalol: 53% | p=0.3
Vijayalakshmi, 2006^181^ | 94 | 6 months | Amiodarone: 63% Sotalol: 39% | P=0.05

a In patients who had sinus rhythm and were free of adverse effects.

Abbreviations: AE=adverse event; CI=confidence interval; HR=hazard ratio; N=number of participants; NR=not reported

Three studies compared propafenone with sotalol,245,258,261 again with two of these studies reporting a composite outcome of maintenance of sinus rhythm without adverse effects from medication.258,261 One of these studies showed no significant difference in the rate of this outcome,245 while the other two found that the propafenone groups had rates of maintenance of sinus rhythm that were almost twice that of the sotalol groups, although statistical analyses comparing the groups were not reported.258,261

Two studies compared amiodarone with propafenone and evaluated a composite outcome of maintenance of sinus rhythm free from adverse effects from medication.259,261 In both studies, at 1 year amiodarone was better than propafenone for this outcome, but at 2 years propafenone was better. In both studies, investigators described the rate of recurrence of AF as being constant throughout followup for amiodarone, but they described the rate of recurrence of AF on propafenone as being high early on during therapy and then decreasing over time.

One study compared bisoprolol with sotalol and found no significant difference in the rate of maintenance of sinus rhythm.269 The final study found that the addition of verapamil to treatment with either amiodarone or flecainide increased the rate of AF-free survival compared with treatment with either antiarrhythmic agent alone.249 These studies suggest that amiodarone appears to be better sotalol but no different from propafenone, but given the diversity in comparisons and the imprecision of the findings, the strength of evidence was considered low.

###### Recurrence of AF

Ten studies comparing primarily pharmacological interventions for AF included recurrence (or prevalence) of AF as an outcome (Table 17).180,224,230,241,245,249,256,259,261,269 Three of these studies compared amiodarone with sotalol.180,241,261 Of these three studies, one showed no statistically significant difference between treatment arms at 4 months or 1 year;241 however, the other two studies reported a higher rate of recurrence of AF among those on sotalol compared with amiodarone—68 percent versus 33 percent at 2 years of followup in one study (no statistical test reported),261 and 68 percent versus 48 percent at 1 year in the other study (p=0.001).180

Table 17 Studies assessing recurrence of AF

Study | Sample Size (N) | Time Point | Results | P-Value
Kochiadakis, 2000^261^ | 214 | 2 years | Amiodarone: 33.3% Sotalol: 68% Propafenone: 37.5% | NR
Kochiadakis, 2000^261^ | 214 | Monthly rate | Amiodarone: 1.96% Sotalol: 6.56% Propafenone: 4.73% | p=0.046 (Amiodarone vs. Propafenone)
Roy, 2000^230^ | 403 | Mean followup 468 days | Amiodarone vs. Sotalol/Propafenone HR 0.43 (95% CI, 0.32 to 0.57) | p<0.001
Singh, 2005^180^ | 665 | 1 year | Amiodarone: 48% Sotalol: 68% | p=0.002
Singh, 2005^180^ | 665 | Median days to recurrence | Amiodarone: 487 Sotalol: 74 | p=0.002
Bellandi, 2001^245^ | 300 | 12 months | Propafenone: 32% Sotalol: 23% | p=0.16
Bellandi, 2001^245^ | 300 | Mean time to recurrence | Propafenone: 105 +/- 96 days Sotalol: 109 +/- 86 days | NR
Plewan, 2001^269^380 | 128 | 12 months | Bisoprolol: 42% Sotalol: 41% | NS
Plewan, 2001^269^380 | 128 | Mean days to recurrence | Bisoprolol:38 ± 74 Sotalol: 49 ± 87 | NS
Plewan, 2001^269^380 | 128 | Monthly rate | Bisoprolol: 3.5% Sotalol:3.4% | NS
Anonymous, 2003^241^ | 256 | 4 months | Amiodarone: 17% Sotalol: 22% | p=0.356
Anonymous, 2003^241^ | 256 | 1 year | Amiodarone: 12% Sotalol:19% | p=0.14
De Simone, 2003^249^ | 324 | 3 months | Amiodarone: 32% Flecainide: 38% Amiodarone + Verapamil: 20% Flecainide + Verapamil: 21% | p=0.08 (Amiodarone vs. Amiodarone + Verapamil) p=0.02 (Flecainide vs. Flecainide + Verapamil)
Katritsis, 2003^256^ | 90 | 12 months | Bisoprolol: 46% Carvedilol: 32% | p=0.486
Kochiadakis, 2004^259^ | 146 | 24 months | Amiodarone vs. Propafenone; actual rates not given | p=0.058
Le Heuzey, 2010^224^ | 504 | 12 months | Dronedarone: 36.5% Amiodarone: 24.3% | NR

Abbreviations: AF=atrial fibrillation; CI=confidence interval; HR=hazard ratio; NR=not reported; NS=not statistically significant

Two studies compared sotalol with propafenone.245,261 The rate of recurrence of AF for sotalol versus propafenone was not statistically significantly different in 1 study at 12 months (23% vs. 32%; P=NS).245 Another study reported a higher rate with sotalol than with propafenone at 2 years (68% vs. 37.5%), but no statistical analysis was reported.261

Two studies compared the effects of amiodarone versus propafenone; one found a statistically significantly higher monthly rate of recurrence with propafenone;261 the other found no significant difference in recurrence between the two drugs.259 In line with the results of these two studies, another study evaluated the risk of recurrence of AF for amiodarone compared with either sotalol or propafenone over approximately 1 year and found a significantly lower risk among those on amiodarone, with a hazard ratio (HR) of 0.43 (95% CI, 0.32 to 0.57).230

Two studies compared amiodarone to different antiarrhythmic therapy.224,249 One compared amiodarone versus flecainide, with and without verapamil added to either treatment. The rate of recurrence of AF did not differ at 3 months between amiodarone and flecainide (no statistical test reported). The addition of verapamil to flecainide reduced the rate of recurrence significantly compared with flecainide alone (21% vs. 38%, p=0.02); however, the addition of verapamil to amiodarone did not change the rate of recurrence of AF compared with amiodarone alone.249 One study compared amiodarone with dronedarone and found a higher rate of recurrence with dronedarone, but the statistical analysis was not reported.224

Finally, two studies compared the beta-blocker bisoprolol with either another beta-blocker or an antiarrhythmic agent.256,269 One study showed no significant difference between rates of recurrence at 1 year between bisoprolol and carvedilol;256 the other showed no significant difference between rates of recurrence of AF with bisoprolol versus sotalol.269

These findings suggest that amiodarone appears to be better than dronedarone or sotalol, but no different from propafenone (low strength of evidence).

###### All-Cause Mortality

All-cause mortality was reported in 5 studies during a period of 6 months to 5 years (Table 18). Three of the studies compared amiodarone with sotalol, and statistical comparisons were either not performed or treatments were not found to be statistically significantly different.180,181,241 In one study, amiodarone was compared with sotalol or propafenone and no statistical analyses were done.230 In another study amiodarone was compared with dronedarone but no statistical analyses were done224 Differences in followup, comparisons, and findings resulted in insufficient strength of evidence for this outcome.

Table 18 Studies reporting all-cause mortality as an outcome

Study | Sample Size (N) | Time Point | Results | P-Value
Roy, 2000^230^ | 403 | Mean followup 468 days | Amiodarone: 4% Sotalol or propafenone: 4% | NR
Anonymous, 2003^241^ | 256 | 5 years (mean followup 3.84 years) | Amiodarone: 11% Sotalol: 19% | 0.081
Singh, 2005^180^ | 665 | Over 1 year | Amiodarone: 5% Sotalol: 6% | NR
Vijayalakshmi, 2006^181^ | 94 | 6 months | Amiodarone: 0% Sotalol: 0% | NR
Le Heuzey, 2010^224^ | 504 | 6 months (median treatment of 7 months) | Amiodarone: 2% Dronedarone: 0.8% | NR

Abbreviation: n=number of participants; NR=not reported

###### Cardiovascular Mortality

Four studies reported arrhythmic deaths as an outcome at 1–5 years of followup.180,230,241,260 Three studies compared amiodarone with sotalol and found no difference between these treatment arms180,241,260. In one study, there was no statistically significant difference in arrhythmic death between those receiving amiodarone vs. sotalol (4% vs. 4%, p=0.900).241 Another study reported 2 percent of patients in the amiodarone group had sudden death and 3 percent in the sotalol group (no statistical test reported),180 while the third study reported no deaths in either treatment arm due to proarrhythmia or sudden death.260 In the study comparing amiodarone with either sotalol or propafenone, 1.5 percent of patients in the amiodarone group died, presumably due to arrhythmia, while 0.5 percent of patient in the sotalol/propafenone group died due to arrhythmia (no statistical test done).230 There was a low strength of evidence rating for there being no difference between evaluated pharmacological agents.

###### CV Hospitalizations

No studies reported generally on CV hospitalizations. One study230 compared the proportion of patients with AF hospitalizations between amiodarone and either sotalol or propafenone. The rate of AF hospitalization was lower with amiodarone than with sotalol or propafenone (14% vs. 25%, p-value not reported). In addition, the mean number of days to AF hospitalization was lower with amiodarone than with sotalol/propafenone (0.47 vs.0.97, p=0.01) (low strength of evidence).

###### Control of AF symptoms

One study230 assessed control of AF symptoms using the Atrial Fibrillation Severity Scale (AFSS) and found no statistically significant difference in mean scores between amiodarone versus sotalol or propafenone arms (12.8 vs. 15.3, p=NS; low strength of evidence).

###### Quality of Life

Two studies reported outcomes related to quality of life.180,230 One study comparing amiodarone with sotalol found no significant changes in quality-of-life scores for any treatment group during the 1 year of followup except for a significant decrease in the mental health score for patients on amiodarone, which differed significantly from those on sotalol (p=0.005).180 The other study230 compared treatment with amiodarone versus treatment with either sotalol or propafenone230 and found that all quality-of-life measures improved during 3 months of followup, but these improvements did not differ by treatment arm (low strength of evidence).

###### Stroke

The outcome of stroke was reported in only two studies, and in both stroke was described as an adverse event and was not evaluated as a primary or secondary outcome.180,230 In the study comparing amiodarone with either sotalol or propafenone, patients on sotalol or propafenone experienced a greater number of strokes and intracranial hemorrhages than did those on amiodarone (9 vs.1 patient, p=0.01), and most of these patients were taking warfarin at the time of the event.230 In a study comparing amiodarone with sotalol, there was no significant difference between treatment arms for the number of minor or major stroke episodes per person-year (0.87 with amiodarone vs. 2.03 with sotalol, p=NS)180 (insufficient strength of evidence).

###### Composite Outcome (Recurrence of AF or Adverse Drug Effect)

Five studies assessed a composite outcome of recurrence of AF or adverse drug event (Table 19).224,258-261 Two studies compared sotalol with propafenone,258,261 two compared amiodarone with propafenone,259,261 two compared amiodarone with sotalol,260,261 and one compared amiodarone with dronedarone.224 In several of these comparisons, statistical analyses were not conducted.

Table 19 Studies reporting a composite outcome of recurrence of AF or adverse drug effect

Study | Sample Size (N) | Time Point | Results | P-Value
Kochiadakis, 2000^260^ | 186 | 1 month | Amiodarone: 28% Sotalol: 13% | NR
Kochiadakis, 2000^260^ | 186 | 12 months | Amiodarone: 41.5% Sotalol: 64% | NR
Kochiadakis, 2000^260^ | 186 | 24 months | Amiodarone: 87.4% Sotalol: 90% | NR
Kochiadakis, 2000^260^ | 186 | Mean monthly progression | Amiodarone: 4.9% Sotalol: 8.3% | p<0.001
Kochiadakis, 2000^260^ | 186 | 1-year event-free rate in patients free of AEs | Amiodarone: 60.3% Sotalol: 37.9% | NR
Kochiadakis, 2000^260^ | 186 | 2-year event-free rate in patients free of AEs | Amiodarone: 42.6% Sotalol: 13.3% | NR
Kochiadakis, 2000^261^ | 214 | 12 months | Amiodarone: 29.1% Sotalol: 60.8% Propafenone: 39.6% | NR
Kochiadakis, 2000^261^ | 214 | 24 months | Amiodarone: 55.3% Sotalol: 80.4% Propafenone: 40% | NR
Kochiadakis, 2000^261^ | 214 | Mean monthly rate | Amiodarone: 3.05% Sotalol: 7.2% Propafenone: 4.93% | p=0.33 (Amiodarone vs. Propafenone p<0.001 (Amiodarone vs. Sotalol) p<0.001 (Sotalol vs. Propafenone)
Kochiadakis, 2004^258^ | 254 | 12 months | Sotalol: 50% Propafenone: 59% | NR
Kochiadakis, 2004^258^ | 254 | Mean monthly progression | Sotalol: 5.26% Propafenone: 3.13% | NR
Kochiadakis, 2004^259^ | 146 | 12 months | Amiodarone: 28% Propafenone: 55% | NR
Kochiadakis, 2004^259^ | 146 | 24 months | Amiodarone: 44% Propafenone: 58% | NR
Kochiadakis, 2004^259^ | 146 | Mean monthly progression | Amiodarone: 3.18% Propafenone: 3.96% | 0.44
Le Heuzey224 | 504 | Time to event (12 months) | Dronedarone vs. Amiodarone HR 1.59 (95% CI, 1.29 to 1.98) | p<0.0001

Abbreviations: AE=adverse event; CI=confidence interval; HR=hazard ratio; N=number of participants; NR=not reported

Both studies comparing sotalol with propafenone found that patients on propafenone had a lower rate of the composite outcome than did patients on sotalol at 12–30 months; however, statistical analyses comparing these rates were not done.258,261 In one of these studies a statistical analysis was done to compare the mean monthly rate of progression to AF or adverse drug effects. The rate among those on propafenone was significantly lower than the rate among those on sotalol (4.93% vs.7.20%, p<0.001).261

In the two studies comparing amiodarone with propafenone, the proportion of patients with the composite outcome was higher in patients receiving propafenone versus amiodarone except in one study261 at 24 months; however, statistical analyses were not done for any of these comparisons.259,261 Both studies also assessed the mean monthly progression to AF or adverse drug effects and found a lower rate with amiodarone than with propafenone; however, the difference was not statistically significant in either study (amiodarone 3.18% vs. propafenone 3.96%, p=0.44;^259^ amiodarone 3.05% vs. propafenone 4.93%, p=0.33^261^).

Two studies compared amiodarone with sotalol. Rates of the composite outcome were higher in those receiving sotalol versus amiodarone except at 1 month (see Table 19), but statistical analyses were not reported. The mean monthly rate of progression to AF or adverse drug events was statistically significantly lower for amiodarone as compared with sotalol in both studies (see Table 19).

In the study comparing amiodarone with dronedarone, there was a statistically significantly higher rate of recurrence of AF or premature drug discontinuation due to side effects or lack of efficacy at 1 year among those on dronedarone compared with amiodarone (HR 1.59; 95% CI, 1.29 to 1.98, p<0.0001).224

###### Adverse Events

Of the 13 studies primarily assessing pharmacological agents for maintaining sinus rhythm, 11 (85%) provided some information on adverse drug events in 2,647 patients.180,181,224,230,241,245,258-261,269 Arrhythmic death (including sudden cardiac arrest) and all-cause mortality are described above as separate outcomes. Of these 11 studies, 5 incorporated adverse drug events resulting in drug discontinuation into a composite outcome with recurrence of AF to assess the effectiveness of the drug(s).224,258-261 These studies had a more robust method of collecting adverse drug event information than other studies. The method of collecting adverse drug events and the definitions of adverse drugs varied between studies, making comparison between studies and summaries of studies challenging.

In the 11 studies, 1,093 patients received amiodarone, 813 received sotalol, 326 received propafenone, 249 received dronedarone, 64 received bisoprolol, and 202 received either sotalol or propafenone. In these 2,747 patients, only 7 proarrhythmias were reported (1 in a patient receiving propafenone and 6 in patients receiving sotalol).245,258,269 Tachycardia was reported in 3 patients (2 receiving propafenone, and 1 receiving either sotalol or propafenone).230,259 Bradycardia was one of the more commonly reported adverse drug reactions, reported in 161 patients in 9 studies (73 on dronedarone, 61 on amiodarone, 15 on sotalol, 2 on propafenone, 3 on bisoprolol, and 7 on either sotalol or propafenone).224,230,241,245,258-261,269 Hypothyroidism or hyperthyroidism were reported in 5 studies that included 668 patients with amiodarone, 138 patients with propafenone, 136 with sotalol, 249 with dronedarone, and 202 with either sotalol or propafenone.224,230,259-261 Hypothyroidism was reported in 29 patients with amiodarone and 2 patients with dronedarone. Hyperthyroidism was reported in 20 patients with amiodarone.

###### Results in Specific Subgroups of Interest

Six studies report outcomes by treatment arm for subgroups of patients based on characteristics such as age, sex, type of AF, duration of AF, left atrial size, and presence of heart disease.180,230,258-261 With few exceptions, the results of primary outcomes did not change by subgroup. Four studies compared amiodarone with sotalol.180,230,260,261 In one of these, the probability of remaining in sinus rhythm continued to be significantly greater among patients without ischemic heart disease on amiodarone compared with sotalol (p<0.001), but this probability was not statistically significantly different among patients with a history of ischemic heart disease (0.53).180 In the other three subgroup analyses comparing amiodarone with sotalol, there was no such difference between patients with and without a history of heart disease.230,260,261 In one of three studies comparing amiodarone with sotalol and reporting subgroup analyses by age, there was a higher rate of recurrence of AF or adverse effects from the medication among those patients taking sotalol who were >65 years of age compared with those who were ≤65 years of age (p=0.04).260 Finally, in the study comparing the effect of amiodarone with propafenone on the outcome of the recurrence of AF alone, there was a statistically significant lower rate of recurrence among women on amiodarone compared with women on propafenone, but this difference was not seen among males.259

### Strength of Evidence

Our review identified 83 studies that evaluated the comparative safety and effectiveness of rhythm-control procedures and drugs for maintenance of sinus rhythm. These studies demonstrated that among patients with AF, there is high strength of evidence that rhythm control using transcatheter PVI is superior to rhythm control using antiarrhythmic medications in reducing recurrent AF over 12 months of followup in patients with paroxysmal AF. This evidence is strongest in younger patients with little to no structural heart disease, and with no or mild enlargement of the left atrium. The evidence also suggested that the duration of AF is an important predictor of response to PVI. Our findings support the findings of prior reviews. Our review also examined whether complex fractionated atrial electrogram (CFAE) ablation in addition to PVI increases the odds of maintaining sinus rhythm during followup compared with PVI only. Based on data from 9 RCTs, we found that CFAE ablation in addition to PVI did not demonstrate a statistically significant increase in maintenance of sinus rhythm compared with PVI only. By combining data from nine RCTs, our review is the largest to date to address this question. Unlike prior reviews, our review showed a potential benefit, but this finding did not reach statistical significance, and we therefore concluded that CFAE ablation in addition to PVI did not increase maintenance of sinus rhythm compared with PVI alone. This difference is largely driven by the inclusion of two recent studies216,223 not included in prior reviews which did not demonstrate a benefit of CFAE. This finding could inform clinical decision making regarding the extent of ablation during a PVI procedure, especially given the potential for reduced atrial mechanical function from more scarring with CFAE. The low strength of evidence rating for this comparison and outcome underscores the importance of conducting well-powered and designed RCTs to address this issue definitively. Our review also evaluated surgical Maze and determined that there is moderate evidence that rhythm control using surgical Maze at the time of other cardiac surgery (specifically, mitral valve surgery) is superior to mitral valve surgery alone in reducing AF recurrence. We also found that there is strong evidence that rhythm control using PVI at the time of cardiac surgery is superior to cardiac surgery alone or in combination with antiarrhythmic drugs (AADs) or with catheter ablation in reducing AF recurrence over 12 months of followup in patients with persistent AF. Our findings support exploring these interventions further with regard to their effect on final outcomes and in different patient populations.

Despite the wide range of antiarrhythmic drugs available in the United States, our review identified only 18 comparative studies eligible for inclusion. Amiodarone, sotalol, and propafenone were the most commonly used antiarrhythmic drugs in RCTs assessing the pharmacological maintenance of sinus rhythm. Only one study (a substudy of the AFFIRM study) systematically assessed differences in all-cause mortality between antiarrhythmic drugs and found no statistically significant difference between amiodarone and sotalol. With regard to maintaining sinus rhythm or decreasing recurrences of AF, amiodarone did not appear to be different from propafenone in the two studies of fair quality that reported results on this comparison. Comparisons of other antiarrhythmic drugs were infrequent and often led to conflicting results. The superiority of one antiarrhythmic medication over another has been debated for years and there has been a long-standing need to review and synthesize the evidence surrounding the comparative effectiveness of different antiarrhythmic medications at maintaining sinus rhythm. However, due to the number of studies, small number of patients enrolled in the studies, and heterogeneity across studies in terms of both patient populations and treatments, the results are inconclusive.

Overall, across the included studies additional evidence is needed to explore the impact of available interventions on final clinical outcomes (e.g., all-cause mortality, stroke, heart failure, and LVEF) as well as long-term outcomes beyond 12 months. Finally, the evidence base is limited in terms of the exploration of subgroups of interest.

Tables 20 and 21 summarize the strength of evidence for the outcomes of interest comparing rhythm-control procedures and drugs for maintenance of sinus rhythm. For those comparisons where the number of studies was sufficient to estimate a summary effect, we were able to have greater confidence in our findings.

Table 20 Strength of evidence domains for rhythm-control procedures

Outcome | Number of Studies (Subjects) | Domains Pertaining to SOE | | | | SOE and Magnitude of Effect (95% CI)
Outcome | Number of Studies (Subjects) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect (95% CI)
Transcatheter PVI vs. AADs
Maintenance of Sinus Rhythm | 8 (921) | RCT/Low | Consistent | Direct | Precise | SOE=High OR 6.51 (95% CI, 3.22 to 13.16) favoring transcatheter PVI
All-Cause Mortality | 1 (69) | RCT/Moderate | NA | Direct | Imprecise | SOE=Insufficient
CV Hospitalizations | 2 (268) | RCT/Low | Consistent | Direct | Imprecise | SOE=Moderate Both studies demonstrated significant increase in CV hospitalizations in the AAD arm vs. PVI
AF Hospitalizations | 1 (67) | RCT/Moderate | NA | Direct | Imprecise | SOE=Insufficient
Quality of Life | 6 (647) | RCT/Low | Inconsistent | Direct | Imprecise | SOE=Insufficient
Mixed Embolic Events Including Stroke | 2 (140) | RCT/Low | Consistent | Direct | Imprecise | SOE=Low No embolic events in either the PVI or AAD arm
Bleeding Events | 1 (67) | RCT/Moderate | NA | Direct | Imprecise | SOE=Insufficient
Transcatheter PVI Using Different Types of Ablation Catheters
Maintenance of Sinus Rhythm | 3 (264) | RCT/Low | Consistent | Direct | Imprecise | SOE=Low No difference between different types of ablation catheters
Recurrence of AF | 1 (102) | RCT/Low | NA | Direct | Imprecise | SOE=Low No difference between a multipolar circular ablation catheter and a point-by-point PVI with an irrigated tip ablation catheter (p=0.8)
Stroke | 1 (82) | RCT/Moderate | NA | Direct | Imprecise | SOE=Insufficient
Transcatheter Circumferential PVI vs. Transcatheter Segmental PVI
Restoration of Sinus Rhythm | 1 (80) | RCT/Moderate | NA | Direct | Imprecise | SOE=Insufficient
Maintenance of Sinus Rhythm | 5 (500) | RCT/Low | Inconsistent | Direct | Imprecise | SOE=Low OR 1.31 (95% CI, 0.59 to 2.93) demonstrating a potential benefit of circumferential PVI which did not reach statistical significance
All-Cause Mortality | 1 (110) | RCT/Low | NA | Direct | Imprecise | SOE=Low No events in either arm after 48 months
Transcatheter PVI With CTI ablation vs. Transcatheter PVI Without CTI ablation
Recurrence of AF | 2 (257) | RCT/Low | Inconsistent | Direct | Imprecise | SOE=Insufficient
Transcatheter PVI With CFAE Ablation vs. Transcatheter PVI Without CFAE Ablation
Restoration of Sinus Rhythm | 2 (247) | RCT/Low | Consistent | Direct | Imprecise | SOE=Low 2 studies showing significant benefit of CFAE arm
Maintenance of Sinus Rhythm | 9 (817) | RCT/Low | Inconsistent | Direct | Imprecise | SOE=Low OR 1.48 (95% CI, 0.74 to 2.98) showing a potential benefit of CFAE which did not reach statistical significance
Quality of Life | 1 (60) | RCT/Moderate | NA | Direct | Imprecise | SOE=Insufficient
Stroke | 1 (144) | RCT/Low | NA | Direct | Imprecise | SOE=Low No events in any arm after 16 months
Transcatheter PVI vs. Transcatheter PVI With Additional Ablation Sites Other Than CTI and CFAE and Transcatheter PVI Involving all Four PVs vs. Transcatheter PVI Involving Arrhythmogenic PVs Only
Restoration of Sinus Rhythm | 2 (384) | RCT/Low | Consistent | Direct | Imprecise | SOE=Insufficient
Maintenance of Sinus Rhythm | 15 (1,926) | RCT/Moderate | Inconsistent | Direct | Imprecise | SOE=Insufficient
Recurrence of AF | 6 (572) | RCT/Moderate | Inconsistent | Direct | Imprecise | SOE=Insufficient
All-Cause Mortality | 2 (405) | RCT/Low | Inconsistent | Direct | Imprecise | SOE=Insufficient
Quality of Life | 2 (152) | RCT/Low | Consistent | Direct | Imprecise | SOE=Low No significant difference between arms in 2 studies
Stroke | 2 (361) | RCT/Low | Inconsistent | Direct | Imprecise | SOE=Insufficient
Transcatheter PVI Alone vs. Transcatheter PVI Plus Postablation AADs
Recurrence of AF | 2 (217) | RCT/Low | Inconsistent | Direct | Imprecise | SOE=Insufficient
AF Hospitalizations | 1 (110) | RCT/Low | NA | Direct | Imprecise | SOE=Low No difference between arms
Surgical Maze vs. Standard of Care (Mitral Valve Surgery)
Maintenance of Sinus Rhythm | 7 (361) | RCT/Low | Inconsistent | Direct | Precise | SOE=Moderate OR 5.80 (95% CI, 1.79 to 18.81) demonstrating large and significant benefit of Maze
All-Cause Mortality | 6 (387) | RCT/Low | Inconsistent | Direct | Imprecise | SOE=Low OR 1.97 (95% CI, 0.81 to 4.80) demonstrating potentially greater mortality with Maze which did not reach statistical significance
Heart Failure Symptoms | 1 (30) | RCT/Moderate | NA | Direct | Imprecise | SOE=Insufficient
Stroke | 1 (30) | RCT/Moderate | NA | Direct | Imprecise | SOE=Insufficient
Mixed Embolic Events Including Stroke | 1 (67) | RCT/Moderate | NA | Direct | Imprecise | SOE=Insufficient
Bleeding Events | 1 (60) | RCT/Moderate | NA | Direct | Imprecise | SOE=Insufficient
PVI at the Time of Cardiac Surgery vs. Cardiac Surgery Alone or in Combination with AADs or Catheter Ablation
Restoration of Sinus Rhythm | 3 (181) | RCT/Low | Consistent | Direct | Precise | SOE=High OR 12.30 (95% CI, 1.31 to 115.29) demonstrating statistically significant benefit of PVI at time of cardiac surgery
Maintenace of Sinus Rhythm | 8 (532) | RCT/Low | Consistent | Direct | Precise | SOE=High OR 3.91 (95% CI, 1.54 to 9.91) demonstrating statistically significant benefit of PVI at time of cardiac surgery
All-Cause Mortaltiy | 2 (88) | RCT/Low | Consistent | Direct | Imprecise | SOE=Low 2 studies showing no difference between groups
CV Mortality | 1 (97) | RCT/Moderate | NA | Direct | Imprecise | SOE=Insufficient
Quality of Life | 2 (229) | RCT/Low | Inconsistent | Direct | Imprecise | SOE=Insufficient
Stroke | 2 (140) | RCT/Low | Consistent | Direct | Imprecise | SOE=Low 2 studies showing no difference between groups
Bleeding Events | 1 (43) | RCT/Moderate | NA | Direct | Imprecise | SOE=Insufficient

Abbreviations: AAD(s)=antiarrhythmic drug(s); AF=atrial fibrillation; CFAE=complex fractionated atrial electrogram; CI=confidence interval; CTI=cavotricuspid isthmus; CV=cardiovascular; NA=not applicable; OR=odds ratio; PV(s)=pulmonary vein(s); PVI=pulmonary vein isolation; RCT=randomized controlled trial; SOE=strength of evidence

Table 21 Strength of evidence domains for pharmacological rhythm-control therapies

Outcome | Number of Studies (Subjects) | Domains Pertaining to SOE | | | | SOE and Magnitude of Effect (95% CI)
Outcome | Number of Studies (Subjects) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect (95% CI)
Pharmacological Therapy in Which Electrical Cardioversion is a Key Component of the Treatment
Maintenance of Sinus Rhythm | 1 (168) | RCT/Low | NA | Direct | Imprecise | SOE=Insufficient
Recurrence of AF | 4 (414) | RCT/Moderate | Inconsistent | Direct | Imprecise | SOE=Insufficient
All-Cause Mortality | 1 (168) | RCT/Low | NA | Direct | Imprecise | SOE=Insufficient
Quality of Life | 1 (144) | RCT/Low | NA | Direct | Imprecise | SOE=Insufficient
Stroke | 1 (168) | RCT/Low | NA | Direct | Imprecise | SOE=Insufficient
Comparison of Pharmacological Agents
Maintenance of Sinus Rhythm | 9 (2,095) | RCT/Low | Consistent | Direct | Imprecise | SOE=Low Amiodarone appears better than sotalol, but no different from propafenone
Recurrence of AF | 10 (3,223) | RCT/Low | Inconsistent | Direct | Imprecise | SOE=Low Amiodarone appears better than dronedarone or sotalol, but no different from propafenone
All-Cause Mortality | 5 (2,076) | RCT/Low | Inconsistent | Direct | Imprecise | SOE=Insufficient
CV Mortality | 4 (1,664) | RCT/Low | Consistent | Direct | Imprecise | SOE=Low No difference between study arms in arrhythmic deaths
AF Hospitalizations | 1 (403) | RCT/Low | NA | Direct | Imprecise | SOE=Low Rate and mean length of stay of AF hospitalization were lower with amiodarone than with sotalol/propafenone
Control of AF Symptoms | 1 (403) | RCT/Low | NA | Direct | Imprecise | SOE=Low No difference between amiodarone versus sotalol or propafenone
Quality of Life | 2 (1,068) | RCT/Low | Consistent | Direct | Imprecise | SOE=Low No significant difference in either study
Stroke | 2 (1,068) | RCT/Low | Inconsistent | Direct | Imprecise | SOE=Insufficient

Abbreviations: AF=atrial fibrillation; CI=confidence interval; CV=cardiovascular; NA=not applicable; RCT=randomized controlled trial; SOE=strength of evidence

## Key Question 6 Rate- Versus Rhythm-Control Therapies

KQ 6: What are the comparative safety and effectiveness of rate-control therapies compared with rhythm-control therapies in patients with atrial fibrillation? Do the comparative safety and effectiveness of these therapies differ among specific patient subgroups of interest?

### Key Points

- Based on evidence from 3 RCTs (2 good, 1 fair quality) involving 439 patients, pharmacological rate-control strategies with antiarrhythmic medications are superior to rhythm-control strategies in reducing cardiovascular hospitalizations (high strength of evidence).
- Among patients with AF, there is evidence that pharmacological rate-control strategies are comparable in efficacy to rhythm-control strategies with antiarrhythmic medications with regard to their effect on the following outcomes:
  ○ Cardiovascular mortality: Based on data from 5 RCTs (all good quality) involving 2,405 patients (moderate strength of evidence)
  ○ Stroke: Based on data from 8 RCTs (5 good, 2 fair, 1 poor quality) involving 6,424 patients (moderate strength of evidence)
  ○ All-cause mortality: Based on data from 8 RCTs (5 good, 2 fair, 1 poor quality) involving 6,372 patients (moderate strength of evidence)
- With regard to heart failure symptoms, there is evidence showing a potential benefit of rhythm-control strategies with antiarrhythmic medications compared with pharmacological rate-control strategies, which did not reach statistical significance. This finding is based on evidence from 4 RCTs (2 good, 2 fair quality) involving 1,700 patients (low strength of evidence).
- Not surprisingly, based on evidence from 7 RCTs (4 good, 2 fair, 1 poor quality) involving 1,473 patients, rhythm-control strategies with antiarrhythmic medications are significantly more efficacious at maintaining sinus rhythm than pharmacological rate-control strategies (high strength of evidence).
- There was insufficient strength of evidence about outcomes comparing a rhythm-control strategy that involved PVI with a rate-control strategy that involved AVN ablation and implantation of a pacemaker (one good-quality study) or rate-controlling medications (one poor-quality study).

### Description of Included Studies

A total of 14 RCTs were included in our analysis (Appendix Table F-6), 12 that explored a rhythm-control strategy using pharmacological therapy versus a rate-control strategy,155,156,159,295-303 and 2 that compared a rhythm-control strategy with PVI versus a rate-control strategy that involved AVN ablation and implantation of a pacemaker in one case304 and rate-controlling medications in the other (poor-quality) study.305 Ten studies were multicenter RCTs. Eleven included outpatients,155,156,159,295,296,299-302,304,305 one included inpatients,298 and two did not report information on setting.297,303 Ten studies were conducted in Europe;156,159,295-300,303,305 one was conducted in the United States and Canada only;155 one was conducted in Asia only;302 one was conducted in the United States, Canada, South America, and Israel;301 and one did not report the location.304 Nine studies were of good quality,155,156,159,296,297,299-301,304 three were of fair quality,295,298,302 and two were of poor quality.303,305 The funding source was the government for three studies,155,299,305 industry for three studies,295,297,302 government and industry for three studies,156,301,304 and not reported for five studies.159,296,298,300,303 Studies enrolled patients between 1995 and 2009. The number of patients included ranged from 41^305^ to 4,060^155^ for a total of 7,556 patients across the 14 studies. The mean age of study participants ranged from 39 years302 to 72 years.300 When reported, study duration varied from 2 years to 6 years.155,295,299,301,302

Five studies included only patients with persistent AF,156,159,298-300 one included only patients with paroxysmal AF,295 two included both patients with paroxysmal and those with persistent AF,301,304 and six studies did not explicitly report type of AF.155,296,297,302,303,305 Duration of AF at baseline ranged from 103 days297 to 3,285 days.295 Four studies included only patients with heart failure.300,301,304,305 None of the remaining studies was limited to a special population.155,156,159,295-299,302,303

Regarding interventions, one study mandated the use of diltiazem as a rate-controlling medication versus amiodarone as a rhythm-controlling medication.297 Six studies allowed different rate-controlling medications in the rate-control strategy (usually digoxin, beta blockers and calcium channel blockers), and different antiarrhythmic medications, along with electrical cardioversion when needed, in the rhythm-control strategy. The latter strategy restricts the use of some of these antiarrhythmic medications based on the presence of absence of structural heart disease like heart failure and/or coronary artery disease.155,156,296,299,301,303 Two studies mandated AVN ablation and pacemaker as the rate-controlling strategy and allowed different antiarrhythmic medications for rhythm control.159,295 In one of these two studies, AVN ablation with VVIR pacing was specified as the rate-control strategy, and AVN ablation with DDDR pacing and use of antiarrhythmic medication was specified as the rhythm-control strategy.159 One study specified using amiodarone with or without electrical cardioversion in the rhythm-control group versus digoxin or metoprolol in the rate-control group.298 One study specified using placebo versus amiodarone in the rhythm-control group, with or without cardioversion, and diltiazem in the rate-control group.302 One study specified using digoxin or beta blockers in the rate-control group versus amiodarone with or without electrical cardioversion in the rhythm-control group.300 One study compared PVI as the rhythm-control strategy with AVN ablation and pacemaker as the rate-control strategy.304 Finally, one poor-quality study compared PVI as the rhythm-control strategy versus rate-controlling medications.305

### Detailed Synthesis

#### Comparison 1 Rate-Control Strategy Versus Rhythm-Control Strategy Using Antiarrhythmic Drugs

##### Quantitative Analysis

This analysis addressed the comparative safety and effectiveness of a rate-control strategy versus a rhythm-control strategy using pharmacological agents. We identified 12 RCTs for this comparison, and the available data were deemed appropriate for meta-analysis for the following outcomes: maintenance of sinus rhythm, all-cause mortality, cardiovascular mortality, cardiovascular hospitalizations, heart failure symptoms, stroke, mixed embolic events including stroke, and bleeding events.

###### Maintenance of Sinus Rhythm

Seven studies representing 1,473 patients were included in our meta-analysis of maintenance of sinus rhythm.156,159,295,296,299,302,303 Figure 19 shows that the OR of rate control versus rhythm control for maintenance of sinus rhythm was 0.18 (95% CI, 0.11 to 0.28), demonstrating a statistically significant greater ability of patients on rhythm-control strategies to be maintained in sinus rhythm as compared with those on rate-control strategies (high strength of evidence). There was evidence of heterogeneity; however, the demonstration of a benefit of rhythm-control strategies was consistent, and therefore this heterogeneity did not reduce the strength of evidence rating. The Q-value was 213.49 for 3 degrees of freedom, p=0.036.

Figure 19 Forest plot of maintenance of sinus rhythm for rate- versus rhythm-control strategies

Abbreviation: CI=confidence interval

This figure displays a forest plot of four studies comparing rate control versus rhythm control for presence or worsening of heart failure symptoms. The odds ratio was 0.777 (95% CI, 0.419 to 1.444), showing a potential benefit of a rhythm-control strategy which did not reach statistical significance.

###### Ventricular Rate Control

Control of ventricular rate was reported by two studies.156,299 In one,299 ventricular rate control was significantly better in the rhythm-control group than in the rate-control group (mean±SD, 79.1±8.6 bpm vs. 85.8±7.5 bpm; p<0.003). In the other study,156 the mean heart rate in the resting state was significantly better during rhythm control (73±18 bpm) than during rate control (82±16 bpm) (low strength of evidence).

###### All-Cause Mortality

Eight studies representing 6,413 patients were included in our meta-analysis of all-cause mortality.155,159,296,298,299,301-303 Figure 20 shows that the OR of rate control versus rhythm control for all-cause mortality was 1.34 (95% CI, 0.89 to 2.02), demonstrating a potential benefit of a rhythm-control strategy which did not reach statistical significance. In addition, 6 of the 8 studies had ORs that crossed 1, including 6,069 (95%) of the patients. There was also significant heterogeneity. The Q-value was 21.71 for 7 degrees of freedom (p=0.003). We therefore assessed these eight studies as demonstrating comparable efficacy between rate and rhythm control strategies for all-cause mortality (moderate strength of evidence).

Figure 20 Forest plot of all-cause mortality for rate- versus rhythm-control strategies

Abbreviation: CI=confidence interval

This figure displays a forest plot of three studies comparing rate control versus rhythm control for cardiovascular hospitalizations. The summary odds ratio was 0.245 (95% CI, 0.138 to 0.434), demonstrating a statistically significant reduction in cardiovascular hospitalizations for patients on rate-control strategies.

###### Cardiovascular Mortality

Five studies representing 2,405 patients were included in our meta-analysis of cardiovascular mortality.156,159,296,299,301 Figure 21 shows that the OR of rate control versus rhythm control for cardiac mortality was 0.96 (95% CI, 0.77 to 1.20), showing no difference between rate- and rhythm-control strategies on cardiovascular mortality (moderate strength of evidence). Although the point estimates were inconsistent and confidence intervals wide for two of the included studies,296,299 there was no evidence of heterogeneity, and therefore our strength of evidence rating was not lowered. The Q-value was 3.55 for 4 degrees of freedom, p=0.470.

Figure 21 Forest plot of cardiovascular mortality for rate- versus rhythm-control strategies

Abbreviation: CI=confidence interval

This figure displays a forest plot of seven studies comparing rate control versus rhythm control for maintenance of sinus rhythm. The summary odds ratio was 0.175 (95% CI, 0.111 to 0.278), demonstrating a statistically significant benefit of rate-control strategies for this outcome.

###### Myocardial Infarction

One study295 compared rates of MI in patients treated with rate control (2.9%) versus patients treated with rhythm control (1.5%) and found no significant difference between the two groups, although the numbers were very small (p=0.51). This outcome was examined by only one other study,159 which also showed no significant difference between rate control and rhythm control (5.8% vs. 10%). The small number of studies and sample size resulted in a low strength of evidence rating.

###### Cardiovascular Hospitalizations

A meta-analysis of three studies159,295,296 representing 439 patients found an OR of 0.25 (95% CI, 0.14 to 0.43) for cardiovascular hospitalizations (Figure 22), demonstrating a statistically significant reduction in cardiovascular hospitalizations for patients on rate-control strategies compared with rhythm-control strategies (high strength of evidence). There was no evidence of heterogeneity (Q-value=2.83 for 2 degrees of freedom, p=0.243).

Figure 22 Forest plot of cardiovascular hospitalizations for rate- versus rhythm-control strategies

Abbreviation: CI=confidence interval

This figure displays a forest plot of eight studies comparing rate control versus rhythm control for stroke. The summary odds ratio was 0.994 (95% CI, 0.759 to 1.302), demonstrating no difference between strategies for this outcome.

One study301 reported specifically on AF hospitalizations. After 3 years of followup, AF hospitalizations were significantly higher in the rhythm-control group than in the rate-control group (14% vs. 9%; p=0.001) Lack of additional studies resulted in an insufficient strength of evidence rating.

###### Heart Failure Symptoms

Four studies representing 1,700 patients were included in our meta-analysis of the presence or worsening of heart failure symptoms.159,295,301,302 Figure 23 shows that the OR of rate control versus rhythm control for presence or worsening of heart failure symptoms was 0.78 (95% CI, 0.42 to 1.44), showing a potential benefit of a rhythm-control strategy which did not reach statistical significance (low strength of evidence). There was no evidence of heterogeneity (Q-value=5.4 for 3 degrees of freedom, p=0.145).

Figure 23 Forest plot of heart failure symptoms for rate- versus rhythm-control strategies

Abbreviation: CI=confidence interval

This figure displays a forest plot of three studies comparing rate control versus rhythm control for mixed embolic events (including stroke). The summary odds ratio was 1.235 (95% CI, 0.372 to 4.096), demonstrating a potentially higher number of embolic events in the rhythm-control strategies; however, this impact did not reach statistical significance.

###### Quality of Life/Functional Status

Quality of life/functional status or control of AF symptoms was assessed in nine studies using a variety of instruments and metrics.155,156,295-297,299,300,302,303 Two of these studies299,302 demonstrated a statistically significant benefit of rhythm-control strategies on quality of life or functional status. None of the other studies demonstrated a significant difference between the two strategies. The variation in metrics and findings resulted in an insufficient strength of evidence rating for this outcome.

###### Stroke

Eight studies representing 6,424 patients were included in our meta-analysis of stroke.155,159,295,296,298,299,301,303 Figure 24 shows that the OR of rate control versus rhythm control for stroke was 0.99 (95% CI, 0.76 to 1.30), demonstrating no difference between rate- and rhythm-control strategies in stroke outcomes (moderate strength of evidence). There was no evidence of heterogeneity, but the findings were mostly driven by one large good-quality RCT contributing 4,060 patients, which was inconsistent with several of the smaller studies, reducing our confidence in the finding and therefore the strength of evidence. The Q-value was 7.02 for 7 degrees of freedom, p=0.427.

Figure 24 Forest plot of stroke for rate- versus rhythm-control strategies

Abbreviation: CI=confidence interval

This figure displays a forest plot of five studies comparing rate control versus rhythm control for bleeding. The summary odds ratio was 1.095 (95% CI, 0.867 to 1.383), demonstrating no statistically significant difference between strategies for this outcome.

###### Mixed Embolic Events Including Stroke

Three studies representing 866 patients were included in our meta-analysis of mixed embolic events including stroke.156,298,303 Figure 25 shows that the OR of rate control versus rhythm control for mixed embolic events (including stroke) was 1.24 (95% CI, 0.37 to 4.10), demonstrating a potential reduction in embolic events in the rhythm-control strategies; however, this impact did not reach statistical significance and had a wide confidence interval, and therefore the finding is to be viewed with caution (low strength of evidence). There was significant heterogeneity driven by a poor-quality study which lacked sufficient detail to evaluate the applicability of the findings to our population of interest, which therefore lowered the strength of evidence rating. The Q-value was 8.57 for 32 degrees of freedom, p=0.014.

Figure 25 Forest plot of mixed embolic events for rate- versus rhythm-control strategies

Abbreviation: CI=confidence interval

This figure displays a forest plot of eight studies comparing rate control versus rhythm control for all-cause mortality. The summary odds ratio was 1.343 (95% CI, 0.893 to 2.020), with 6 of the 8 studies showing comparable efficacy amongst the two strategies.

###### Bleeding Events

Five studies representing 5,072 patients were included in our meta-analysis of bleeding events.155,156,296,299,302 Figure 26 shows that the OR of rate control versus rhythm control for bleeding 1.10 (95% CI, 0.87 to 1.38), demonstrating no difference between rate- and rhythm-control strategies for this outcome (moderate strength of evidence). There was no evidence of heterogeneity. The Q-value was 1.49 for 3 degrees of freedom, p=0.684.

Figure 26 Forest plot of bleeding events for rate- versus rhythm-control strategies

Abbreviation: CI=confidence interval

This figure displays a forest plot of five studies comparing rate control versus rhythm control for cardiac mortality. The summary odds ratio was 0.959 (95% CI, 0.769 to 1.196), showing no difference between strategies for this outcome.

###### Composite Outcomes

Six studies examined composite outcomes.155,156,159,296,299,301 Because the components of these outcomes differed across studies, combining them was deemed inappropriate. One study296 examined a composite of all-cause mortality, stroke, embolic events other than stroke, and cardiopulmonary resuscitation, and found no significant difference in this outcome between patients managed with a rate-control strategy (10%) and those managed with a rhythm-control strategy (9%; p=0.99). Another study299 examined a composite of all-cause mortality, mixed embolic events including stroke, and bleeding events including hemorrhagic stroke. During a mean followup of 1.7 years, investigators found no difference in this outcome between patients treated with a rate-control strategy and those treated with a rhythm-control strategy (OR 1.98; 95% CI, 0.28 to 22.30; p>0.71). In another study,159 after a mean followup of 26.6±9.5 months, the primary outcome of stroke or cardiovascular death occurred in 6 out of 52 patients with VVIR pacing (5.3% per year), and in 6 out of 50 patients with DDDR pacing and antiarrhythmic drugs (5.9% per year; p=0.9). One study301 found that time to the composite outcome of all-cause mortality, heart failure symptoms, and stroke was not significantly different between the rate-control group and the rhythm-control group (HR 0.90; 95% CI, 0.77 to 1.06; p=0.20). In another study,156 the risk of the combined outcome of cardiovascular mortality, mixed embolic events including stroke, bleeding events (including hemorrhagic stroke), heart failure, need for a permanent pacemaker, and severe adverse events from antiarrhythmic medications was not significantly different between the rate-control group and the rhythm-control group (17.2% vs. 22.6%; 90% CI, -11.0 to 0.4%; p value NR). Finally, one study155 compared the rate of the combined outcome of all-cause mortality, stroke, bleeding events (including hemorrhagic stroke) and adverse drug reactions in patients treated with rate-control and patients treated with rhythm control and found no significant difference between the two groups over a mean followup of 3.5 years (20.5% for rate control vs. 21.9%; p=0.33 for rhythm control).

###### Adverse Events

Reporting of adverse events was inconsistent across studies. Hypotension and hypothyroidism were not reported as adverse events in any of the studies. Adverse events that were reported included: hyperthyroidism (0 in rate control vs. 2 in rhythm control299), bradycardia (4 studies, with results as follows: rate control 4.2% vs. rhythm control 6.0% [p=0.001];155 rate control 3% vs. rhythm control 1.9% [p=NS];299 rate control 3% vs. rhythm control 6% [p=NR];301 and rate control 3% vs. rhythm control 8% [p=NR]).156 Proarrhythmia was reported (0 in rate control 4 in rhythm control, p=NS).299 In one study,155 the rate of pulmonary toxicity was 4.6 percent (1.7% in the rate-control group vs. 7.3% in the rhythm-control group; p<0.001). In one study,297 10 patients (4%) developed ocular toxicity, all in the rhythm-control arm. In one study,155 heart failure occurred in 2.1 percent of patients treated with rate control versus 2.7 percent of patients treated with rhythm control (p=0.58). In the same study,155 corrected QT interval prolongation >520 ms occurred in 0.3 percent of patients in the rate-control group versus 1.9 percent in the rhythm-control group (p<0.001).

#### Comparison 2 Rate-Control Strategy Versus Rhythm-Control Strategy Using PVI

##### Maintenance of Sinus Rhythm

In one poor-quality study,305 after 6 months of followup, PVI resulted in maintenance of sinus rhythm in only 50 percent of patients (compared with none in the medical treatment arm). In the other study,304 which was rated as good quality, maintenance of sinus rhythm at 6 months was higher among patients who underwent PVI versus those who underwent AVN ablation and a biventricular pacemaker implantation (71% vs. 0%, p value=NR) (low strength of evidence).

##### Quality of Life/Functional Status

In one study,304 functional capacity was measured by the 6-minute walk test, and investigators found that the distance increased from 269±54 m at baseline to 340±49 m at 6 months in the group that underwent PVI as compared with 281±44 m to 297±36 m in the group that underwent AVN with biventricular pacing (p<0.001). In the group that underwent PVI, the mean MLWHF score improved, with a reduction from 89±12 at baseline to 60±8 at 6 months. In the group that underwent AVN ablation with biventricular pacing, a reduction was observed from 89±11 at baseline to 82±14 at 6 months (p<0.001for the comparison between the two groups).

The second study,305 which was rated as poor quality, also examined 6-minute walk distance and quality of life based on the Kansas City Cardiomyopathy Questionnaire, SF-36 physical component summary, and SF-36 mental component summary at 6 months. PVI did not improve quality of life as assessed by the 6-minute walk distance (mean change of 20.1 m for PVI vs. 21.4 m in the rate-control group; p=0.96), the Kansas City Cardiomyopathy Questionnaire (mean change in score of 7.1 in PVI vs. 5.6 in the rate-control group; p=0.81), or the SF-36 mental component (mean within-group change 0.4±9.5 for PVI vs. 5.9±8.5 for the rate-control group; p=0.07). The SF-36 physical component was significantly better in the PVI group than in the rate-control group (mean within-group change 4±9.5 for PVI vs. -1±4.4 for the rate-control group; p=0.042) (insufficient strength of evidence).

##### Composite Outcomes

One study304 compared the composite outcome of quality of life/functional status as defined by the 6-minute walk distance, Minnesota Living With Heart Failure (MLWHF) questionnaire, and LVEF in patients who received PVI as the rhythm-control strategy versus patients who underwent AVN ablation and pacemaker as the rate-control strategy. After 6 months of followup, this outcome was significantly better in the PVI group (p=0.017).

Reported separately, the components of the primary outcome were as follows: For PVI as compared with AVN ablation with biventricular pacing, the LVEF was significantly higher (35±9% vs. 28±6%; p<0.001), the 6-minute walking distance significantly longer (340±49 m vs. 297±36 m; p<0.001), and the MLWHF scores significantly better (60±8 vs. 82±14; p<0.001).

##### Adverse Events

In one poor-quality study,305 within 6 months of followup, the rate of serious complications related to PVI was 15 percent versus 0 percent in the rate-control group. These complications included: one stroke, two cardiac tamponades, and one readmission to the hospital within 1 week after the procedure. In the other study,304 bleeding occurred in 4 patients (9.8%) in the PVI group versus 2 (5%) in the AVN ablation and biventricular pacemaker implantation group. One patient in the PVI group developed pulmonary edema, and one patient in the AVN ablation with biventricular pacemaker implantation group developed pneumothorax.

#### Results in Specific Subgroups of Interest

No results were reported for outcomes of interest in specific subgroups of interest.

### Strength of Evidence

Our review identified 14 studies that evaluated the comparative safety and effectiveness of rate- and rhythm-control strategies among patients with AF. We were able to quantitatively synthesize 12 of these RCTs focusing on pharmacological rate- and rhythm-control strategies and explore the comparative safety and effectiveness of the interventions. Evidence supported the comparable effectiveness of rate- and rhythm-control strategies in terms of the impact on all-cause mortality, cardiovascular mortality, and stroke. Our analysis is the largest to date addressing this issue and provides further confirmation that rate-control strategies and rhythm-control strategies have comparable effectiveness in patients who are similar to patients enrolled in the included RCTs, i.e., older patients with mild symptoms from AF. Evidence was high that rhythm-control strategies are more effective than rate-control strategies for maintaining sinus rhythm, while rate-control strategies were associated with decreased cardiovascular hospitalizations.

Our review identified only two studies comparing a rhythm-control strategy that involved PVI with a rate-control strategy that involved atrioventricular node (AVN) ablation and implantation of a pacemaker or rate-controlling medications. Findings of these two studies were inconsistent, and evidence was insufficient to determine the comparative effectiveness of the studied interventions.

Table 22 summarizes the strength of evidence for the outcomes of interest comparing rate-control and rhythm-control strategies. Most outcomes of interest were explored quantitatively through meta-analyses using low risk of bias RCTs. We lowered our strength of evidence rating in some of the findings because of inconsistent results across RCTs and wide confidence intervals of the summary effect estimates.

Table 22 Strength of evidence domains for rhythm versus rate control

Outcome | Number of Studies (Subjects) | Domains Pertaining to SOE | | | | SOE and Magnitude of Effect (95% CI)
Outcome | Number of Studies (Subjects) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect (95% CI)
Rate vs. Rhythm Control Using AADs
Maintenance of Sinus Rhythm | 7 (1,473) | RCT/Low | Consistent | Direct | Precise | SOE=High OR 0.18 (95% CI, 0.11 to 0.28) favoring rhythm-control strategies
Ventricular Rate Control | 2 (727) | RCT/Low | Consistent | Direct | Imprecise | SOE=Low Significantly better in rhythm-control strategies
All-Cause Mortality | 8 (6,372) | RCT/Low | Inconsistent | Direct | Precise | SOE=Moderate OR 1.34 (95% CI, 0.89 to 2.02) demonstrating a potential benefit of a rhythm-control strategy which did not reach statistical significance. Since 6 of the 8 studies had ORs that crossed 1 (including 95% of the patients), and given significant heterogeneity, we assessed these studies as demonstrating no difference between rate- and rhythm-control strategies.
CV Mortality | 5 (2,405) | RCT/Low | Inconsistent | Direct | Precise | SOE=Moderate OR 0.96 (95% CI, 0.77 to 1.20) demonstrating no difference between rate- and rhythm-control strategies
Myocardial Infarction | 2 (246) | RCT/Low | Consistent | Direct | Imprecise | SOE=Low Both studies showed no significant difference between rate- and rhythm-control strategies
CV hospitalizations | 3 (439) | RCT/Low | Consistent | Direct | Precise | SOE=High OR 0.25 (95% CI, 0.14 to 0.43) favoring rate-control strategies
Heart Failure Symptoms | 4 (1,700) | RCT/Low | Inconsistent | Direct | Imprecise | SOE=Low OR 0.78 (95% CI, 0.42 to 1.44) showing a potential benefit of rhythm control which did not reach statistical significance
Quality of Life | 9 (5,806) | RCT/Low | Inconsistent | Direct | Imprecise | SOE=Insufficient
Stroke | 8 (6,424) | RCT/Low | Inconsistent | Direct | Precise | SOE=Moderate OR 0.99 (95% CI, 0.76 to 1.30) demonstrating no difference between rate- and rhythm-control strategies
Mixed Embolic Events Including Stroke | 3 (866) | RCT/Low | Inconsistent | Direct | Imprecise | SOE=Low OR 1.24 (95% CI, 0.37 to 4.09) demonstrating a potential benefit of rhythm-control strategies which did not reach statistical significance
Bleeding Events | 5 (5,072) | RCT/Low | Inconsistent | Direct | Precise | SOE=Moderate OR 1.10 (95% CI, 0.87 to 1.38) demonstrating no difference between rate- and rhythm-control strategies
Rate vs. Rhythm Control Using PVI
Maintenance of Sinus Rhythm | 2 (122) | RCT/Moderate | Consistent | Direct | Imprecise | SOE=Low Significantly better in rhythm-control strategies (OR not reported)
Quality of Life | 2 (122) | RCT/Moderate | Inconsistent | Direct | Imprecise | SOE=Insufficient

Abbreviations: AAD(s)=antiarrhythmic drug(s); CI=confidence interval; CV=cardiovascular; OR=odds ratio; NA=not applicable; PVI=pulmonary vein isolation; RCT=randomized controlled trial; SOE=strength of evidence