# References

1 Fuster V, Ryden LE, Cannom DS, et al. ACC/AHA/ESC 2006 Guidelines for the Management of Patients with Atrial Fibrillation: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines and the European Society of Cardiology Committee for Practice Guidelines (Writing Committee to Revise the 2001 Guidelines for the Management of Patients With Atrial Fibrillation): developed in collaboration with the European Heart Rhythm Association and the Heart Rhythm Society. Circulation. 2006;114(7):e257-354. [pmid: 16908781].
2 Go AS, Hylek EM, Phillips KA, et al. Prevalence of diagnosed atrial fibrillation in adults: national implications for rhythm management and stroke prevention: the AnTicoagulation and Risk Factors in Atrial Fibrillation (ATRIA) Study. JAMA. 2001;285(18):2370-5. [pmid: 11343485].
3 Furberg CD, Psaty BM, Manolio TA, et al. Prevalence of atrial fibrillation in elderly subjects (the Cardiovascular Health Study). Am J Cardiol. 1994;74(3):236-41. [pmid: 8037127].
4 Krahn AD, Manfreda J, Tate RB, et al. The natural history of atrial fibrillation: incidence, risk factors, and prognosis in the Manitoba Follow-Up Study. Am J Med. 1995;98(5):476-84. [pmid: 7733127].
5 Poole-Wilson PA, Swedberg K, Cleland JG, et al. Comparison of carvedilol and metoprolol on clinical outcomes in patients with chronic heart failure in the Carvedilol Or Metoprolol European Trial (COMET): randomised controlled trial. Lancet. 2003;362(9377):7-13. [pmid: 12853193].
6 Maggioni AP, Latini R, Carson PE, et al. Valsartan reduces the incidence of atrial fibrillation in patients with heart failure: results from the Valsartan Heart Failure Trial (Val-HeFT). Am Heart J. 2005;149(3):548-57. [pmid: 15864246].
7 Wang TJ, Larson MG, Levy D, et al. Temporal relations of atrial fibrillation and congestive heart failure and their joint influence on mortality: the Framingham Heart Study. Circulation. 2003;107(23):2920-5. [pmid: 12771006].
8 Singh SN, Tang XC, Singh BN, et al. Quality of life and exercise performance in patients in sinus rhythm versus persistent atrial fibrillation: a Veterans Affairs Cooperative Studies Program Substudy. J Am Coll Cardiol. 2006;48(4):721-30. [pmid: 16904540].
9 Dorian P, Jung W, Newman D, et al. The impairment of health-related quality of life in patients with intermittent atrial fibrillation: implications for the assessment of investigational therapy. J Am Coll Cardiol. 2000;36(4):1303-9. [pmid: 11028487].
10 Chung MK, Shemanski L, Sherman DG, et al. Functional status in rate- versus rhythm-control strategies for atrial fibrillation: results of the Atrial Fibrillation Follow-Up Investigation of Rhythm Management (AFFIRM) Functional Status Substudy. J Am Coll Cardiol. 2005;46(10):1891-9. [pmid: 16286177].
11 Hagens VE, Ranchor AV, Van Sonderen E, et al. Effect of rate or rhythm control on quality of life in persistent atrial fibrillation. Results from the Rate Control Versus Electrical Cardioversion (RACE) Study. J Am Coll Cardiol. 2004;43(2):241-7. [pmid: 14736444].
12 Wolf PA, Abbott RD, Kannel WB. Atrial fibrillation as an independent risk factor for stroke: the Framingham Study. Stroke. 1991;22(8):983-8. [pmid: 1866765].
13 Lin HJ, Wolf PA, Kelly-Hayes M, et al. Stroke severity in atrial fibrillation. The Framingham Study. Stroke. 1996;27(10):1760-4. [pmid: 8841325].
14 Fuster V, Ryden LE, Cannom DS, et al. ACC/AHA/ESC 2006 guidelines for the management of patients with atrial fibrillation: full text: a report of the American College of Cardiology/American Heart Association Task Force on practice guidelines and the European Society of Cardiology Committee for Practice Guidelines (Writing Committee to Revise the 2001 guidelines for the management of patients with atrial fibrillation) developed in collaboration with the European Heart Rhythm Association and the Heart Rhythm Society. Europace. 2006;8(9):651-745. [pmid: 16987906].
15 Institute of Medicine. 100 Initial Priority Topics for Comparative Effectiveness Research. June. 2009. http://iom.edu/∼/media/Files/Report%20Files/2009/ComparativeEffectivenessResearchPriorities/Stand%20Alone%20List%20of%20100%20CER%20Priorities%20-%20for%20web.pdf. September 8, 2011.
16 Wann LS, Curtis AB, January CT, et al. 2011 ACCF/AHA/HRS focused update on the management of patients with atrial fibrillation (Updating the 2006 Guideline): a report of the American College of Cardiology Foundation/American Heart Association Task Force on Practice Guidelines. Heart Rhythm. 2011;8(1):157-76. [pmid: 21182985].
17 Van Gelder IC, Groenveld HF, Crijns HJ, et al. Lenient versus strict rate control in patients with atrial fibrillation. N Engl J Med. 2010;362(15):1363-73. [pmid: 20231232].
18 Calkins H, Kuck KH, Cappato R, et al. 2012 HRS/EHRA/ECAS expert consensus statement on catheter and surgical ablation of atrial fibrillation: recommendations for patient selection, procedural techniques, patient management and follow-up, definitions, endpoints, and research trial design: a report of the Heart Rhythm Society (HRS) Task Force on Catheter and Surgical Ablation of Atrial Fibrillation Developed in partnership with the European Heart Rhythm Association (EHRA), a registered branch of the European Society of Cardiology (ESC) and the European Cardiac Arrhythmia Society (ECAS); and in collaboration with the American College of Cardiology (ACC), American Heart Association (AHA), the Asia Pacific Heart Rhythm Society (APHRS), and the Society of Thoracic Surgeons (STS). Endorsed by the governing bodies of the American College of Cardiology Foundation, the American Heart Association, the European Cardiac Arrhythmia Society, the European Heart Rhythm Association, the Society of Thoracic Surgeons, the Asia Pacific Heart Rhythm Society, and the Heart Rhythm Society. Heart Rhythm. 2012;9(4):632-96. e21. [pmid: 22386883].
19 Kong MH, Lopes RD, Piccini JP, et al. Surgical Maze procedure as a treatment for atrial fibrillation: a meta-analysis of randomized controlled trials. Cardiovasc Ther. 2010;28(5):311-26. [pmid: 20370795].
20 Brenyo A, Link MS, Barsheshet A, et al. Cardiac resynchronization therapy reduces left atrial volume and the risk of atrial tachyarrhythmias in MADIT-CRT (Multicenter Automatic Defibrillator Implantation Trial with Cardiac Resynchronization Therapy). J Am Coll Cardiol. 2011;58(16):1682-9. [pmid: 21982313].
21 Hoppe UC, Casares JM, Eiskjaer H, et al. Effect of cardiac resynchronization on the incidence of atrial fibrillation in patients with severe heart failure. Circulation. 2006;114(1):18-25. [pmid: 16801461].
22 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=318. October 31, 2011.
23 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. PLoS Med. 2009;6(7):e1000097. [pmid: 19621072].
24 Anonymous. Evidence-based Practice Center Systematic Review Protocol. Project Title: Treatment of Atrial Fibrillation. Amended May 22, 2011. www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=946. June 14, 2012.
25 McNamara RL, Bass EB, Miller MR, et al. Management of New Onset Atrial Fibrillation. Evidence Report/Technology Assessment No. 12. (prepared by the Johns Hopkins University Evidence-based Practice Center in Baltimore, MD, under Contract No. 290-97-0006). AHRQ Publication Number 01-E026. Rockville, MD. Agency for Healthcare Research and Quality. January. 2001. www.ncbi.nlm.nih.gov/books/NBK33108. October 30, 2012.
26 McNamara RL, Bass EB, Miller MR, et al. Management of new onset atrial fibrillation. Evid Rep Technol Assess (Summ). 2000;(12):1-7. [pmid: 11471248].
27 McNamara RL, Tamariz LJ, Segal JB, et al. Management of atrial fibrillation: review of the evidence for the role of pharmacologic therapy, electrical cardioversion, and echocardiography. Ann Intern Med. 2003;139(12):1018-33. [pmid: 14678922].
28 Ad N, Cheng DCH, Martin J, et al. Surgical ablation for atrial fibrillation in cardiac surgery: A consensus statement of the international society of minimally invasive cardiothoracic surgery (ISMICS) 2009. Innovations: Technology and Techniques in Cardiothoracic and Vascular Surgery. 2010;5(2):74-83.
29 Anthony KK, Mauro VF. Rate versus rhythm control in atrial fibrillation. Ann Pharmacother. 2004;38(5):839-44. [pmid: 15039475].
30 Argall J, Crawford I. Best evidence topic report. Amiodarone or flecainide for cardioversion in acute onset atrial fibrillation. Emerg Med J. 2004;21(2):199. [pmid: 14988348].
31 Balk EM, Garlitski AC, Alsheikh-Ali AA, et al. Predictors of atrial fibrillation recurrence after radiofrequency catheter ablation: a systematic review. J Cardiovasc Electrophysiol. 2010;21(11):1208-16. [pmid: 20487117].
32 Banerjee A, Marin F, Lip GY. A new landscape for stroke prevention in atrial fibrillation: focus on new anticoagulants, antiarrhythmic drugs, and devices. Stroke. 2011;42(11):3316-22. [pmid: 21998051].
33 Barnett SD, Ad N. Surgical ablation as treatment for the elimination of atrial fibrillation: a meta-analysis. J Thorac Cardiovasc Surg. 2006;131(5):1029-35. [pmid: 16678586].
34 Basu S, Nagendran M, Maruthappu M. How effective is bipolar radiofrequency ablation for atrial fibrillation during concomitant cardiac surgery?. Interact Cardiovasc Thorac Surg. 2012;15(4):741-8. [pmid: 22815321].
35 Bonanno C, Paccanaro M, La Vecchia L, et al. Efficacy and safety of catheter ablation versus antiarrhythmic drugs for atrial fibrillation: a meta-analysis of randomized trials. J Cardiovasc Med (Hagerstown). 2010;11(6):408-18. [pmid: 19834326].
36 Boos CJ, Lane DA, Lip GY. Atrial fibrillation (chronic). Clin Evid (Online). 2008;2008. [pmid: 19450316].
37 Boriani G, Martignani C, Biffi M, et al. Oral loading with propafenone for conversion of recent-onset atrial fibrillation: a review on in-hospital treatment. Drugs. 2002;62(3):415-23. [pmid: 11827557].
38 Brooks AG, Stiles MK, Laborderie J, et al. Outcomes of long-standing persistent atrial fibrillation ablation: a systematic review. Heart Rhythm. 2010;7(6):835-46. [pmid: 20206320].
39 Caldeira D, David C, Sampaio C. Rate versus rhythm control in atrial fibrillation and clinical outcomes: Updated systematic review and meta-analysis of randomized controlled trials. Arch Cardiovasc Dis. 2012;105(4):226-38. [pmid: 22633297].
40 Caldeira D, David C, Sampaio C. Rate vs rhythm control in patients with atrial fibrillation and heart failure: A systematic review and meta-analysis of randomised controlled trials. Eur J Intern Med. 2011;22(5):448-55. [pmid: 21925051].
41 Calkins H, Brugada J, Packer DL, et al. HRS/EHRA/ECAS expert consensus statement on catheter and surgical ablation of atrial fibrillation: recommendations for personnel, policy, procedures and follow-up A report of the Heart Rhythm Society (HRS) Task Force on Catheter and Surgical Ablation of Atrial Fibrillation developed in partnership with the European Heart Rhythm Association (EHRA) and the European Cardiac Arrhythmia Society (ECAS); in collaboration with the American College of Cardiology (ACC), American Heart Association (AHA), and the Society of Thoracic Surgeons (STS). Endorsed and approved by the governing bodies of the American College of Cardiology, the American Heart Association, the European Cardiac Arrhythmia Society, the European Heart Rhythm Association, the Society of Thoracic Surgeons and the Heart Rhythm Society. Europace. 2007;9(6):335-79. [pmid: 17599941].
42 Calkins H, Brugada J, Packer DL, et al. HRS/EHRA/ECAS expert Consensus Statement on catheter and surgical ablation of atrial fibrillation: recommendations for personnel, policy, procedures and follow-up. A report of the Heart Rhythm Society (HRS) Task Force on catheter and surgical ablation of atrial fibrillation. Heart Rhythm. 2007;4(6):816-61. [pmid: 17556213].
43 Calkins H, Reynolds MR, Spector P, et al. Treatment of atrial fibrillation with antiarrhythmic drugs or radiofrequency ablation: two systematic literature reviews and meta-analyses. Circ Arrhythm Electrophysiol. 2009;2(4):349-61. [pmid: 19808490].
44 Camm AJ, Kirchhof P, Lip GY, et al. Guidelines for the management of atrial fibrillation: the Task Force for the Management of Atrial Fibrillation of the European Society of Cardiology (ESC). Europace. 2010;12(10):1360-420. [pmid: 20876603].
45 Camm AJ, Kirchhof P, Lip GYH, et al. Guidelines for the management of atrial fibrillation. Eur Heart J. 2010;31(19):2369-429. [pmid: 20802247].
46 Camm CF, Nagendran M, Xiu PY, et al. How effective is cryoablation for atrial fibrillation during concomitant cardiac surgery?. Interact Cardiovasc Thorac Surg. 2011;13(4):410-4. [pmid: 21791522].
47 Chen Y, Maruthappu M, Nagendran M. How effective is unipolar radiofrequency ablation for atrial fibrillation during concomitant cardiac surgery?. Interact Cardiovasc Thorac Surg. 2012;14(6):843-7. [pmid: 22419797].
48 Cheng JW, Rybak I. Use of digoxin for heart failure and atrial fibrillation in elderly patients. Am J Geriatr Pharmacother. 2010;8(5):419-27. [pmid: 21335295].
49 Chevalier P, Durand-Dubief A, Burri H, et al. Amiodarone versus placebo and class Ic drugs for cardioversion of recent-onset atrial fibrillation: a meta-analysis. J Am Coll Cardiol. 2003;41(2):255-62. [pmid: 12535819].
50 Chiappini B, Di Bartolomeo R, Marinelli G. Radiofrequency ablation for atrial fibrillation: different approaches. Asian Cardiovasc Thorac Ann. 2004;12(3):272-7. [pmid: 15353473].
51 Christiansen CB, Torp-Pedersen C, Kober L. Efficacy and safety of dronedarone: a review of randomized trials. Expert Opin Drug Saf. 2010;9(1):189-99. [pmid: 20001756].
52 Christiansen CB, Torp-Pedersen C, Kober L. Impact of dronedarone in atrial fibrillation and flutter on stroke reduction. Clin Interv Aging. 2010;5:63-9. [pmid: 20396635].
53 Cleland JG, Coletta AP, Buga L, et al. Clinical trials update from the American College of Cardiology meeting 2010: DOSE, ASPIRE, CONNECT, STICH, STOP-AF, CABANA, RACE II, EVEREST II, ACCORD, and NAVIGATOR. Eur J Heart Fail. 2010;12(6):623-9. [pmid: 20498271].
54 Cordina J, Mead G. Pharmacological cardioversion for atrial fibrillation and flutter. Cochrane Database Syst Rev. 2005;(2):CD003713. [pmid: 15846675].
55 Bradley DJ, Shen WK. Atrioventricular junction ablation combined with either right ventricular pacing or cardiac resynchronization therapy for atrial fibrillation: the need for large-scale randomized trials. Heart Rhythm. 2007;4(2):224-32. [pmid: 17275763].
56 Dagres N, Varounis C, Flevari P, et al. Mortality after catheter ablation for atrial fibrillation compared with antiarrhythmic drug therapy. A meta-analysis of randomized trials. Am Heart J. 2009;158(1):15-20. [pmid: 19540387].
57 Dale KM, White CM. Dronedarone: an amiodarone analog for the treatment of atrial fibrillation and atrial flutter. Ann Pharmacother. 2007;41(4):599-605. [pmid: 17389667].
58 Dale KM, White CM. Dronedarone: An anniodarone analog for the treatment of atrial fibrillation and atrial flutter. Ann Pharmacother. 2007;41(4):599-605. [pmid: 17389667].
59 de Denus S, Sanoski CA, Carlsson J, et al. Rate vs rhythm control in patients with atrial fibrillation: a meta-analysis. Arch Intern Med. 2005;165(3):258-62. [pmid: 15710787].
60 Deneer VH, Borgh MB, Kingma JH, et al. Oral antiarrhythmic drugs in converting recent onset atrial fibrillation. Pharm World Sci. 2004;26(2):66-78. [pmid: 15085940].
61 Doyle JF, Ho KM. Benefits and risks of long-term amiodarone therapy for persistent atrial fibrillation: a meta-analysis. Mayo Clin Proc. 2009;84(3):234-42. [pmid: 19252110].
62 Duray GZ, Torp-Pedersen C, Connolly SJ, et al. Effects of dronedarone on clinical outcomes in patients with lone atrial fibrillation: pooled post hoc analysis from the ATHENA/EURIDIS/ADONIS studies. J Cardiovasc Electrophysiol. 2011;22(7):770-6. [pmid: 21288278].
63 Engelmann MD, Pehrson S. Quality of life in nonpharmacologic treatment of atrial fibrillation. Eur Heart J. 2003;24(15):1387-400. [pmid: 12909067].
64 Fernandes S, Paulo S, Vizinho R, et al. The therapeutic approach to paroxysmal or persistent atrial fibrillation: rhythm control versus rate control. A review. Rev Port Cardiol. 2004;23(4):599-611. [pmid: 15224646].
65 Freemantle N, Lafuente-Lafuente C, Mitchell S, et al. Mixed treatment comparison of dronedarone, amiodarone, sotalol, flecainide, and propafenone, for the management of atrial fibrillation. Europace. 2011;13(3):329-45. [pmid: 21227948].
66 Fuster V, Ryden LE, Cannom DS, et al. 2011 ACCF/AHA/HRS focused updates incorporated into the ACC/AHA/ESC 2006 guidelines for the management of patients with atrial fibrillation: a report of the American College of Cardiology Foundation/American Heart Association Task Force on practice guidelines. Circulation. 2011;123(10):e269-367. [pmid: 21382897].
67 Fuster V, Ryden LE, Cannom DS, et al. ACC/AHA/ESC 2006 guidelines for the management of patients with atrial fibrillation--executive summary: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines and the European Society of Cardiology Committee for Practice Guidelines (Writing Committee to Revise the 2001 Guidelines for the Management of Patients With Atrial Fibrillation). J Am Coll Cardiol. 2006;48(4):854-906. [pmid: 16904574].
68 Fuster V, Ryden LE, Cannom DS, et al. ACC/AHA/ESC 2006 Guidelines for the Management of Patients With Atrial Fibrillation. A Report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines and the European Society of Cardiology Committee for Practice Guidelines (Writing Committee to Revise the 2001 Guidelines for the Management of Patients With Atrial Fibrillation). J Am Coll Cardiol. 2006;48(4):e149-e246.
69 Gillis AM, Verma A, Talajic M, et al. Canadian Cardiovascular Society atrial fibrillation guidelines 2010: rate and rhythm management. Can J Cardiol. 2011;27(1):47-59. [pmid: 21329862].
70 Gjesdal K, Vist GE, Bugge E, et al. Curative ablation for atrial fibrillation: a systematic review. Scand Cardiovasc J. 2008;42(1):3-8. [pmid: 18273730].
71 Gronefeld G, Hohnloser SH. Rhythm or rate control in atrial fibrillation: insights from the randomized controlled trials. J Cardiovasc Pharmacol Ther. Suppl 1. 2003;8:S39-44. [pmid: 12746751].
72 Gronefeld G, Hohnloser SH. Towards a consensus in rate versus rhythm control for management of atrial fibrillation: insights from the PIAF trial. Card Electrophysiol Rev. 2003;7(2):113-7. [pmid: 14618032].
73 Gronefeld GC, Hohnloser SH. Beta-blocker therapy in atrial fibrillation. Pacing Clin Electrophysiol. 2003;26(7 Pt 2):1607-12. [pmid: 12914610].
74 Hayward RM, Upadhyay GA, Mela T, et al. Pulmonary vein isolation with complex fractionated atrial electrogram ablation for paroxysmal and nonparoxysmal atrial fibrillation: a meta-analysis. Heart Rhythm. 2011;8(7):994-1000. [pmid: 21397045].
75 Healey JS, Nair GM. Does catheter ablation for atrial fibrillation increase or reduce neurological insult?. Curr Opin Cardiol. 2012;27(1):36-40. [pmid: 22123602].
76 Hilleman DE, Spinler SA. Conversion of recent-onset atrial fibrillation with intravenous amiodarone: a meta-analysis of randomized controlled trials. Pharmacotherapy. 2002;22(1):66-74. [pmid: 11794432].
77 Hoppe UC. Resynchronization therapy in the context of atrial fibrillation: benefits and limitations. J Interv Card Electrophysiol. 2007;18(3):225-32. [pmid: 17450330].
78 Hossack M. Towards evidence based emergency medicine: best BETs from the Manchester Royal Infirmary. BET 4. Beta-blockers or digoxin for rate control of acute atrial fibrillation in the emergency department. Emerg Med J. 2009;26(1):61. [pmid: 19104108].
79 Hoy SM, Keam SJ. Dronedarone. Drugs. 2009;69(12):1647-63. [pmid: 19678715].
80 Jeevanantham V, Ntim W, Navaneethan SD, et al. Meta-analysis of the effect of radiofrequency catheter ablation on left atrial size, volumes and function in patients with atrial fibrillation. Am J Cardiol. 2010;105(9):1317-26. [pmid: 20403486].
81 Kalus JS, Mauro VF. Dofetilide: a class III-specific antiarrhythmic agent. Ann Pharmacother. 2000;34(1):44-56. [pmid: 10669186].
82 Kanji S, Stewart R, Fergusson DA, et al. Treatment of new-onset atrial fibrillation in noncardiac intensive care unit patients: a systematic review of randomized controlled trials. Crit Care Med. 2008;36(5):1620-4. [pmid: 18434899].
83 Khan IA, Mehta NJ, Gowda RM. Amiodarone for pharmacological cardioversion of recent-onset atrial fibrillation. Int J Cardiol. 2003;89(2-3):239-48. [pmid: 12767548].
84 Khan IA. Oral loading single dose flecainide for pharmacological cardioversion of recent-onset atrial fibrillation. Int J Cardiol. 2003;87(2-3):121-8. [pmid: 12559528].
85 Khan IA. Single oral loading dose of propafenone for pharmacological cardioversion of recent-onset atrial fibrillation. J Am Coll Cardiol. 2001;37(2):542-7. [pmid: 11216976].
86 Khargi K, Hutten BA, Lemke B, et al. Surgical treatment of atrial fibrillation; a systematic review. Eur J Cardiothorac Surg. 2005;27(2):258-65. [pmid: 15691679].
87 Khargi K, Keyhan-Falsafi A, Hutten BA, et al. Surgical treatment of atrial fibrillation : a systematic review. Herzschrittmacherther Elektrophysiol. 2007;18(2):68-76. [pmid: 17646938].
88 Kong MH, Piccini JP, Bahnson TD. Efficacy of adjunctive ablation of complex fractionated atrial electrograms and pulmonary vein isolation for the treatment of atrial fibrillation: a meta-analysis of randomized controlled trials. Europace. 2011;13(2):193-204. [pmid: 21037322].
89 Krul SP, Driessen AH, Zwinderman AH, et al. Navigating the mini-maze: Systematic review of the first results and progress of minimally-invasive surgery in the treatment of atrial fibrillation. Int J Cardiol. 2011. Nov. 9. [Epub ahead of print]. [pmid: 22078990].
90 Kumana CR, Cheung BM, Cheung GT, et al. Rhythm vs. rate control of atrial fibrillation meta-analysed by number needed to treat. Br J Clin Pharmacol. 2005;60(4):347-54. [pmid: 16187966].
91 Lafuente-Lafuente C, Longas-Tejero MA, Bergmann JF, et al. Antiarrhythmics for maintaining sinus rhythm after cardioversion of atrial fibrillation. Cochrane Database Syst Rev. 2012;5:CD005049. [pmid: 22592700].
92 Lafuente-Lafuente C, Mouly S, Longas-Tejero MA, et al. Antiarrhythmics for maintaining sinus rhythm after cardioversion of atrial fibrillation. Cochrane Database Syst Rev. 2007;(4):CD005049. [pmid: 17943835].
93 Lafuente-Lafuente C, Mouly S, Longas-Tejero MA, et al. Antiarrhythmic drugs for maintaining sinus rhythm after cardioversion of atrial fibrillation: a systematic review of randomized controlled trials. Arch Intern Med. 2006;166(7):719-28. [pmid: 16606807].
94 le Polain de Waroux JB, Talajic M, Khairy P, et al. Pulmonary vein isolation for the treatment of atrial fibrillation: past, present and future. Future Cardiol. 2010;6(1):51-66. [pmid: 20014987].
95 Lee G. A review of the literature on atrial fibrillation: rate reversion or control?. J Clin Nurs. 2007;16(1):77-83. [pmid: 17181669].
96 Letelier LM, Udol K, Ena J, et al. Effectiveness of amiodarone for conversion of atrial fibrillation to sinus rhythm: a meta-analysis. Arch Intern Med. 2003;163(7):777-85. [pmid: 12695268].
97 Li WJ, Bai YY, Zhang HY, et al. Additional ablation of complex fractionated atrial electrograms after pulmonary vein isolation in patients with atrial fibrillation: a meta-analysis. Circ Arrhythm Electrophysiol. 2011;4(2):143-8. [pmid: 21303900].
98 Lim HS, Hamaad A, Lip GY. Clinical review: clinical management of atrial fibrillation - rate control versus rhythm control. Crit Care. 2004;8(4):271-9. [pmid: 15312210].
99 Lip GY, Watson T. Atrial fibrillation (acute onset). Clin Evid (Online). 2008;2008. [pmid: 19450312].
100 Macdonald DR, Maruthappu M, Nagendran M. How effective is microwave ablation for atrial fibrillation during concomitant cardiac surgery?. Interact Cardiovasc Thorac Surg. 2012;15(1):122-7. [pmid: 22510269].
101 Maund E, McKenna C, Sarowar M, et al. Dronedarone for the treatment of atrial fibrillation and atrial flutter. Health Technol Assess. 2010;14(Suppl. 2):55-62. [pmid: 21047492].
102 McKenna C, Maund E, Sarowar M, et al. Dronedarone for the Treatment of Atrial Fibrillation: A NICE Single Technology Appraisal. Pharmacoeconomics. 2011;30(1):35. [pmid: 22136303].
103 McKenna C, Palmer S, Rodgers M, et al. Cost-effectiveness of radiofrequency catheter ablation for the treatment of atrial fibrillation in the United Kingdom. Heart. 2009;95(7):542-9. [pmid: 19095714].
104 Mead GE, Elder AT, Flapan AD, et al. Electrical cardioversion for atrial fibrillation and flutter. Cochrane Database Syst Rev. 2005;(3):CD002903. [pmid: 16034878].
105 Michelena HI, Powell BD, Brady PA, et al. Gender in atrial fibrillation: Ten years later. Gend Med. 2010;7(3):206-17. [pmid: 20638626].
106 Naccarelli GV, Wolbrette DL, Khan M, et al. Old and new antiarrhythmic drugs for converting and maintaining sinus rhythm in atrial fibrillation: comparative efficacy and results of trials. Am J Cardiol. 2003;91(6A):15D-26D. [pmid: 12670638].
107 Nair GM, Nery PB, Diwakaramenon S, et al. A systematic review of randomized trials comparing radiofrequency ablation with antiarrhythmic medications in patients with atrial fibrillation. J Cardiovasc Electrophysiol. 2009;20(2):138-44. [pmid: 18775040].
108 Nault I, Miyazaki S, Forclaz A, et al. Drugs vs. ablation for the treatment of atrial fibrillation: the evidence supporting catheter ablation. Eur Heart J. 2010;31(9):1046-54. [pmid: 20332181].
109 Nichol G, McAlister F, Pham B, et al. Meta-analysis of randomised controlled trials of the effectiveness of antiarrhythmic agents at promoting sinus rhythm in patients with atrial fibrillation. Heart. 2002;87(6):535-43. [pmid: 12010934].
110 Nikolaidou T, Channer KS. Chronic atrial fibrillation: a systematic review of medical heart rate control management. Postgrad Med J. 2009;85(1004):303-12. [pmid: 19528305].
111 Noheria A, Kumar A, Wylie JV Jr., et al. Catheter ablation vs antiarrhythmic drug therapy for atrial fibrillation: a systematic review. Arch Intern Med. 2008;168(6):581-6. [pmid: 18362249].
112 Novak PG. Effectiveness of catheter ablation versus antiarrhythmic drug therapy for atrial fibrillation. Curr Opin Cardiol. 2009;24(1):9-17. [pmid: 19077814].
113 Page P. Canadian Cardiovascular Society atrial fibrillation guidelines 2010: surgical therapy. Can J Cardiol. 2011;27(1):67-73. [pmid: 21329864].
114 Parkash R, Tang AS, Sapp JL, et al. Approach to the catheter ablation technique of paroxysmal and persistent atrial fibrillation: a meta-analysis of the randomized controlled trials. J Cardiovasc Electrophysiol. 2011;22(7):729-38. [pmid: 21332861].
115 Piccini JP, Hasselblad V, Peterson ED, et al. Comparative efficacy of dronedarone and amiodarone for the maintenance of sinus rhythm in patients with atrial fibrillation. J Am Coll Cardiol. 2009;54(12):1089-95. [pmid: 19744618].
116 Piccini JP, Lopes RD, Kong MH, et al. Pulmonary vein isolation for the maintenance of sinus rhythm in patients with atrial fibrillation: a meta-analysis of randomized, controlled trials. Circ Arrhythm Electrophysiol. 2009;2(6):626-33. [pmid: 20009077].
117 de la Morandiere KP, Morriss H. Paddle position in emergency cardioversion of atrial fibrillation. Emerg Med J. 2005;22(1):44-6. [pmid: 15611544].
118 Reston JT, Shuhaiber JH. Meta-analysis of clinical outcomes of maze-related surgical procedures for medically refractory atrial fibrillation. Eur J Cardiothorac Surg. 2005;28(5):724-30. [pmid: 16143540].
119 Rienstra M, Van Gelder IC. Who, when and how to rate control for atrial fibrillation. Curr Opin Cardiol. 2008;23(1):23-7. [pmid: 18281823].
120 Rodgers M, McKenna C, Palmer S, et al. Curative catheter ablation in atrial fibrillation and typical atrial flutter: systematic review and economic evaluation. Health Technol Assess. 2008;12(34):iii-iv. xi. xiii. 1. 198. [pmid: 19036232].
121 Saborido CM, Hockenhull J, Bagust A, et al. Systematic review and cost-effectiveness evaluation of ‘pill-in-the-pocket’ strategy for paroxysmal atrial fibrillation compared to episodic in-hospital treatment or continuous antiarrhythmic drug therapy. Health Technol Assess. 2010;14(31):iii-iv. 1. 75. [pmid: 20569652].
122 Santangeli P, Di Biase L, Pelargonio G, et al. Catheter ablation of atrial fibrillation: randomized controlled trials and registries, a look back and the view forward. J Interv Card Electrophysiol. 2011;31(1):69-80. [pmid: 21476087].
123 Schilling RJ. Cardioversion of atrial fibrillation: the use of antiarrhythmic drugs. Heart. 2010;96(5):333-8. [pmid: 19910286].
124 Sherman DG. Stroke prevention in atrial fibrillation: pharmacological rate versus rhythm control. Stroke. 2007;38(2 Suppl):615-7. [pmid: 17261701].
125 Skanes AC, Healey JS, Cairns JA, et al. Focused 2012 update of the Canadian Cardiovascular Society atrial fibrillation guidelines: recommendations for stroke prevention and rate/rhythm control. Can J Cardiol. 2012;28(2):125-36. [pmid: 22433576].
126 Slavik RS. Intravenous amiodarone for acute pharmacological conversion of atrial fibrillation in the emergency department. CJEM. 2002;4(6):414-20. [pmid: 17637159].
127 Snow V, Weiss KB, LeFevre M, et al. Management of newly detected atrial fibrillation: a clinical practice guideline from the American Academy of Family Physicians and the American College of Physicians. Ann Intern Med. 2003;139(12):1009-17. [pmid: 14678921].
128 Sullivan RM, Olshansky B. Dronedarone: evidence supporting its therapeutic use in the treatment of atrial fibrillation. Core Evid. 2010;5:49-59. [pmid: 21042542].
129 Tang Y, Yang H, Qiu J. Relationship between brain natriuretic peptide and recurrence of atrial fibrillation after successful electrical cardioversion: a meta-analysis. J Int Med Res. 2011;39(5):1618-24. [pmid: 22117962].
130 Terasawa T, Balk EM, Chung M, et al. Systematic review: comparative effectiveness of radiofrequency catheter ablation for atrial fibrillation. Ann Intern Med. 2009;151(3):191-202. [pmid: 19581635].
131 Testa L, Biondi-Zoccai GG, Dello Russo A, et al. Rate-control vs. rhythm-control in patients with atrial fibrillation: a meta-analysis. Eur Heart J. 2005;26(19):2000-6. [pmid: 15872032].
132 Thrall G, Lane D, Carroll D, et al. Quality of life in patients with atrial fibrillation: a systematic review. Am J Med. 2006;119(5):448 e1-19. [pmid: 16651058].
133 Upadhyay GA, Choudhry NK, Auricchio A, et al. Cardiac resynchronization in patients with atrial fibrillation: a meta-analysis of prospective cohort studies. J Am Coll Cardiol. 2008;52(15):1239-46. [pmid: 18926327].
134 Wilton SB, Leung AA, Ghali WA, et al. Outcomes of cardiac resynchronization therapy in patients with versus those without atrial fibrillation: A systematic review and meta-analysis. Heart Rhythm. 2011;8(7):1088-94. [pmid: 21338711].
135 Zhang Y, Wang Z, Wang W, et al. Efficacy of cardiac autonomic denervation for atrial fibrillation: a meta-analysis. J Cardiovasc Electrophysiol. 2012;23(6):592-600. [pmid: 22429251].
136 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions-Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol. 2010;63(5):513-23. [pmid: 19595577].
137 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. 2011;64(11):1198-207. [pmid: 21463926].
138 Delle Karth G, Geppert A, Neunteufl T, et al. Amiodarone versus diltiazem for rate control in critically ill patients with atrial tachyarrhythmias. Crit Care Med. 2001;29(6):1149-53. [pmid: 11395591].
139 Demircan C, Cikriklar HI, Engindeniz Z, et al. Comparison of the effectiveness of intravenous diltiazem and metoprolol in the management of rapid ventricular rate in atrial fibrillation. Emerg Med J. 2005;22(6):411-4. [pmid: 15911947].
140 Hofmann R, Steinwender C, Kammler J, et al. Effects of a high dose intravenous bolus amiodarone in patients with atrial fibrillation and a rapid ventricular rate. Int J Cardiol. 2006;110(1):27-32. [pmid: 16046015].
141 Khand AU, Rankin AC, Martin W, et al. Carvedilol alone or in combination with digoxin for the management of atrial fibrillation in patients with heart failure?. J Am Coll Cardiol. 2003;42(11):1944-51. [pmid: 14662257].
142 Kochiadakis GE, Kanoupakis EM, Kalebubas MD, et al. Sotalol vs metoprolol for ventricular rate control in patients with chronic atrial fibrillation who have undergone digitalization: a single-blinded crossover study. Europace. 2001;3(1):73-9. [pmid: 11271956].
143 Siu CW, Lau CP, Lee WL, et al. Intravenous diltiazem is superior to intravenous amiodarone or digoxin for achieving ventricular rate control in patients with acute uncomplicated atrial fibrillation. Crit Care Med. 2009;37(7):2174-9. quiz 80. [pmid: 19487941].
144 Capucci A, Villani GQ, Aschieri D, et al. Oral amiodarone increases the efficacy of direct-current cardioversion in restoration of sinus rhythm in patients with chronic atrial fibrillation. Eur Heart J. 2000;21(1):66-73. [pmid: 10610746].
145 Hemels ME, Van Noord T, Crijns HJ, et al. Verapamil versus digoxin and acute versus routine serial cardioversion for the improvement of rhythm control for persistent atrial fibrillation. J Am Coll Cardiol. 2006;48(5):1001-9. [pmid: 16949494].
146 Holming K. The effect of digitalis or a beta-blocker, alone or in combination, on atrial fibrillation at rest and during exercise. Ups J Med Sci. 2001;106(1):77-8. [pmid: 11817566].
147 Lindholm CJ, Fredholm O, Moller SJ, et al. Sinus rhythm maintenance following DC cardioversion of atrial fibrillation is not improved by temporary precardioversion treatment with oral verapamil. Heart. 2004;90(5):534-8. [pmid: 15084552].
148 Simpson CS, Ghali WA, Sanfilippo AJ, et al. Clinical assessment of clonidine in the treatment of new-onset rapid atrial fibrillation: a prospective, randomized clinical trial. Am Heart J. 2001;142(2):E3. [pmid: 11479482].
149 Thomas SP, Guy D, Wallace E, et al. Rapid loading of sotalol or amiodarone for management of recent onset symptomatic atrial fibrillation: a randomized, digoxin-controlled trial. Am Heart J. 2004;147(1):E3. [pmid: 14691441].
150 Tsuneda T, Yamashita T, Fukunami M, et al. Rate control and quality of life in patients with permanent atrial fibrillation: the Quality of Life and Atrial Fibrillation (QOLAF) Study. Circ J. 2006;70(8):965-70. [pmid: 16864926].
151 Wattanasuwan N, Khan IA, Mehta NJ, et al. Acute ventricular rate control in atrial fibrillation: IV combination of diltiazem and digoxin vs. IV diltiazem alone. Chest. 2001;119(2):502-6. [pmid: 11171729].
152 Groenveld HF, Crijns HJ, Rienstra M, et al. Does intensity of rate control influence outcome in persistent atrial fibrillation? Data of the RACE study. Am Heart J. 2009;158(5):785-91. [pmid: 19853699].
153 Van Gelder IC, Wyse DG, Chandler ML, et al. Does intensity of rate-control influence outcome in atrial fibrillation? An analysis of pooled data from the RACE and AFFIRM studies. Europace. 2006;8(11):935-42. [pmid: 16973686].
154 Groenveld HF, Crijns HJ, Van den Berg MP, et al. The effect of rate control on quality of life in patients with permanent atrial fibrillation: data from the RACE II (Rate Control Efficacy in Permanent Atrial Fibrillation II) study. J Am Coll Cardiol. 2011;58(17):1795-803. [pmid: 21996393].
155 Wyse DG, Waldo AL, DiMarco JP, et al. A comparison of rate control and rhythm control in patients with atrial fibrillation. N Engl J Med. 2002;347(23):1825-33. [pmid: 12466506].
156 Van Gelder IC, Hagens VE, Bosker HA, et al. A comparison of rate control and rhythm control in patients with recurrent persistent atrial fibrillation. N Engl J Med. 2002;347(23):1834-40. [pmid: 12466507].
157 Kirkutis A, Poviliunas A, Griciene P, et al. Cardiac rate normalization in chronic atrial fibrillation: comparison of long-term efficacy of treatment with amiodarone versus AV node ablation and permanent His-bundle pacing. Proc West Pharmacol Soc. 2004;47:69-70. [pmid: 15633616].
158 Levy T, Walker S, Mason M, et al. Importance of rate control or rate regulation for improving exercise capacity and quality of life in patients with permanent atrial fibrillation and normal left ventricular function: a randomised controlled study. Heart. 2001;85(2):171-8. [pmid: 11156667].
159 Petrac D, Radic B, Radeljic V, et al. Ventricular pacing vs dual chamber pacing in patients with persistent atrial fibrillation after atrioventricular node ablation: open randomized study. Croat Med J. 2005;46(6):922-8. [pmid: 16342345].
160 Weerasooriya R, Davis M, Powell A, et al. The Australian Intervention Randomized Control of Rate in Atrial Fibrillation Trial (AIRCRAFT). J Am Coll Cardiol. 2003;41(10):1697-702. [pmid: 12767649].
161 Lee SH, Cheng JJ, Chen SA. A randomized, prospective comparison of anterior and posterior approaches to atrioventricular junction modification of medically refractory atrial fibrillation. Pacing Clin Electrophysiol. 2000;23(6):966-74. [pmid: 10879380].
162 Doshi RN, Daoud EG, Fellows C, et al. Left ventricular-based cardiac stimulation post AV nodal ablation evaluation (the PAVE study). J Cardiovasc Electrophysiol. 2005;16(11):1160-5. [pmid: 16302897].
163 Lim KT, Davis MJ, Powell A, et al. Ablate and pace strategy for atrial fibrillation: long-term outcome of AIRCRAFT trial. Europace. 2007;9(7):498-505. [pmid: 17491103].
164 Linde C. How to evaluate quality-of-life in pacemaker patients: problems and pitfalls. Pacing Clin Electrophysiol. 1996;19(4 Pt 1):391-7. [pmid: 8848385].
165 Pocock SJ, Henderson RA, Seed P, et al. Quality of life, employment status, and anginal symptoms after coronary angioplasty or bypass surgery. 3-year follow-up in the Randomized Intervention Treatment of Angina (RITA) Trial. Circulation. 1996;94(2):135-42. [pmid: 8674171].
166 Caine N, Harrison SC, Sharples LD, et al. Prospective study of quality of life before and after coronary artery bypass grafting. BMJ. 1991;302(6775):511-6. [pmid: 2012849].
167 Hawthorne G, Richardson J, Osborne R, et al. The Australian Quality of Life (AQoL) Instrument: Initial Validation. Centre for Health Program Evaluation. Working Paper 66. May. 1997. www.buseco.monash.edu.au/centres/che/doc/wp66.pdf. June 7, 2012.
168 Willund I, Gorkin L, Pawitan Y, et al. Methods for assessing quality of life in the cardiac arrhythmia suppression trial (CAST). Qual Life Res. 1992;1(3):187-201. [pmid: 1301128].
169 Bergner M, Bobbitt RA, Carter WB, et al. The Sickness Impact Profile: development and final revision of a health status measure. Med Care. 1981;19(8):787-805. [pmid: 7278416].
170 Balla I, Petrela E, Kondili A. Pharmacological conversion of recent atrial fibrillation: a randomized, placebo-controlled study of three antiarrhythmic drugs. Anadolu Kardiyol Derg. 2011;11(7):600-6. [pmid: 21911317].
171 Glover BM, Walsh SJ, McCann CJ, et al. Biphasic energy selection for transthoracic cardioversion of atrial fibrillation. The BEST AF Trial. Heart. 2008;94(7):884-7. [pmid: 17591649].
172 Joglar JA, Hamdan MH, Ramaswamy K, et al. Initial energy for elective external cardioversion of persistent atrial fibrillation. Am J Cardiol. 2000;86(3):348-50. [pmid: 10922451].
173 Kawabata VS, Vianna CB, Moretti MA, et al. Monophasic versus biphasic waveform shocks for atrial fibrillation cardioversion in patients with concomitant amiodarone therapy. Europace. 2007;9(2):143-6. [pmid: 17272337].
174 Khaykin Y, Newman D, Kowalewski M, et al. Biphasic versus monophasic cardioversion in shock-resistant atrial fibrillation. J Cardiovasc Electrophysiol. 2003;14(8):868-72. [pmid: 12890051].
175 Kirchhof P, Eckardt L, Loh P, et al. Anterior-posterior versus anterior-lateral electrode positions for external cardioversion of atrial fibrillation: a randomised trial. Lancet. 2002;360(9342):1275-9. [pmid: 12414201].
176 Kirchhof P, Monnig G, Wasmer K, et al. A trial of self-adhesive patch electrodes and hand-held paddle electrodes for external cardioversion of atrial fibrillation (MOBIPAPA). Eur Heart J. 2005;26(13):1292-7. [pmid: 15734772].
177 Korantzopoulos P, Kolettis TM, Papathanasiou A, et al. Propafenone added to ibutilide increases conversion rates of persistent atrial fibrillation. Heart. 2006;92(5):631-4. [pmid: 16159973].
178 Nergardh AK, Rosenqvist M, Nordlander R, et al. Maintenance of sinus rhythm with metoprolol CR initiated before cardioversion and repeated cardioversion of atrial fibrillation: a randomized double-blind placebo-controlled study. Eur Heart J. 2007;28(11):1351-7. [pmid: 17329409].
179 Page RL, Kerber RE, Russell JK, et al. Biphasic versus monophasic shock waveform for conversion of atrial fibrillation: the results of an international randomized, double-blind multicenter trial. J Am Coll Cardiol. 2002;39(12):1956-63. [pmid: 12084594].
180 Singh BN, Singh SN, Reda DJ, et al. Amiodarone versus sotalol for atrial fibrillation. N Engl J Med. 2005;352(18):1861-72. [pmid: 15872201].
181 Vijayalakshmi K, Whittaker VJ, Sutton A, et al. A randomized trial of prophylactic antiarrhythmic agents (amiodarone and sotalol) in patients with atrial fibrillation for whom direct current cardioversion is planned. Am Heart J. 2006;151(4):863 e1-6. [pmid: 16569550].
182 Alatawi F, Gurevitz O, White RD, et al. Prospective, randomized comparison of two biphasic waveforms for the efficacy and safety of transthoracic biphasic cardioversion of atrial fibrillation. Heart Rhythm. 2005;2(4):382-7. [pmid: 15851340].
183 Alp NJ, Rahman S, Bell JA, et al. Randomised comparison of antero-lateral versus antero-posterior paddle positions for DC cardioversion of persistent atrial fibrillation. Int J Cardiol. 2000;75(2-3):211-6. [pmid: 11077136].
184 Ambler JJ, Deakin CD. A randomized controlled trial of efficacy and ST change following use of the Welch-Allyn MRL PIC biphasic waveform versus damped sine monophasic waveform for external DC cardioversion. Resuscitation. 2006;71(2):146-51. [pmid: 16987583].
185 Boodhoo L, Mitchell AR, Bordoli G, et al. DC cardioversion of persistent atrial fibrillation: a comparison of two protocols. Int J Cardiol. 2007;114(1):16-21. [pmid: 16644036].
186 Boos C, Thomas MD, Jones A, et al. Higher energy monophasic DC cardioversion for persistent atrial fibrillation: is it time to start at 360 joules?. Ann Noninvasive Electrocardiol. 2003;8(2):121-6. [pmid: 12848792].
187 Brazdzionyte J, Babarskiene RM, Stanaitiene G. Anterior-posterior versus anterior-lateral electrode position for biphasic cardioversion of atrial fibrillation. Medicina (Kaunas). 2006;42(12):994-8. [pmid: 17211107].
188 Fragakis N, Bikias A, Delithanasis I, et al. Acute beta-adrenoceptor blockade improves efficacy of ibutilide in conversion of atrial fibrillation with a rapid ventricular rate. Europace. 2009;11(1):70-4. [pmid: 18987127].
189 Hassan S, Slim AM, Kamalakannan D, et al. Conversion of atrial fibrillation to sinus rhythm during treatment with intravenous esmolol or diltiazem: a prospective, randomized comparison. J Cardiovasc Pharmacol Ther. 2007;12(3):227-31. [pmid: 17875950].
190 Joseph AP, Ward MR. A prospective, randomized controlled trial comparing the efficacy and safety of sotalol, amiodarone, and digoxin for the reversion of new-onset atrial fibrillation. Ann Emerg Med. 2000;36(1):1-9. [pmid: 10874228].
191 Kafkas NV, Patsilinakos SP, Mertzanos GA, et al. Conversion efficacy of intravenous ibutilide compared with intravenous amiodarone in patients with recent-onset atrial fibrillation and atrial flutter. Int J Cardiol. 2007;118(3):321-5. [pmid: 17049640].
192 Kanoupakis EM, Manios EG, Mavrakis HE, et al. Comparative effects of carvedilol and amiodarone on conversion and recurrence rates of persistent atrial fibrillation. Am J Cardiol. 2004;94(5):659-62. [pmid: 15342304].
193 Manios EG, Mavrakis HE, Kanoupakis EM, et al. Effects of amiodarone and diltiazem on persistent atrial fibrillation conversion and recurrence rates: a randomized controlled study. Cardiovasc Drugs Ther. 2003;17(1):31-9. [pmid: 12843685].
194 Marinsek M, Larkin GL, Zohar P, et al. Efficacy and impact of monophasic versus biphasic countershocks for transthoracic cardioversion of persistent atrial fibrillation. Am J Cardiol. 2003;92(8):988-91. [pmid: 14556881].
195 Mazzocca G, Corbucci G, Venturini E, et al. Is pretreatment with ibutilide useful for atrial fibrillation cardioversion when combined with biphasic shock?. J Cardiovasc Med (Hagerstown). 2006;7(2):124-8. [pmid: 16645372].
196 Mortensen K, Risius T, Schwemer TF, et al. Biphasic versus monophasic shock for external cardioversion of atrial flutter: a prospective, randomized trial. Cardiology. 2008;111(1):57-62. [pmid: 18239394].
197 Rashba EJ, Bouhouch R, MacMurdy KA, et al. Effect of shock polarity on the efficacy of transthoracic atrial defibrillation. Am Heart J. 2002;143(3):541-5. [pmid: 11868063].
198 Rashba EJ, Gold MR, Crawford FA, et al. Efficacy of transthoracic cardioversion of atrial fibrillation using a biphasic, truncated exponential shock waveform at variable initial shock energies. Am J Cardiol. 2004;94(12):1572-4. [pmid: 15589022].
199 Redfearn DP, Skanes AC, Lane J, et al. Signal-averaged P wave reflects change in atrial electrophysiological substrate afforded by verapamil following cardioversion from atrial fibrillation. Pacing Clin Electrophysiol. 2006;29(10):1089-95. [pmid: 17038141].
200 Ricard P, Levy S, Boccara G, et al. External cardioversion of atrial fibrillation: comparison of biphasic vs monophasic waveform shocks. Europace. 2001;3(2):96-9. [pmid: 11333061].
201 Scholten M, Szili-Torok T, Klootwijk P, et al. Comparison of monophasic and biphasic shocks for transthoracic cardioversion of atrial fibrillation. Heart. 2003;89(9):1032-4. [pmid: 12923020].
202 Siaplaouras S, Buob A, Rotter C, et al. Randomized comparison of anterolateral versus anteroposterior electrode position for biphasic external cardioversion of atrial fibrillation. Am Heart J. 2005;150(1):150-2. [pmid: 16084162].
203 Siaplaouras S, Buob A, Rotter C, et al. Impact of biphasic electrical cardioversion of atrial fibrillation on early recurrent atrial fibrillation and shock efficacy. J Cardiovasc Electrophysiol. 2004;15(8):895-7. [pmid: 15333081].
204 Villani GQ, Piepoli MF, Terracciano C, et al. Effects of diltiazem pretreatment on direct-current cardioversion in patients with persistent atrial fibrillation: a single-blind, randomized, controlled study. Am Heart J. 2000;140(3):e12. [pmid: 10966543].
205 De Simone A, Turco P, De Matteis C, et al. Effect of verapamil on secondary cardioversion in patients with early atrial fibrillation recurrence after electrical cardioversion. Am J Cardiol. 2002;90(2):185-7. [pmid: 12106857].
206 Van Noord T, Van Gelder IC, Tieleman RG, et al. VERDICT: the Verapamil versus Digoxin Cardioversion Trial: A randomized study on the role of calcium lowering for maintenance of sinus rhythm after cardioversion of persistent atrial fibrillation. J Cardiovasc Electrophysiol. 2001;12(7):766-9. [pmid: 11469424].
207 Bittner A, Monnig G, Zellerhoff S, et al. Randomized study comparing duty-cycled bipolar and unipolar radiofrequency with point-by-point ablation in pulmonary vein isolation. Heart Rhythm. 2011;8(9):1383-90. [pmid: 21457793].
208 Blomstrom-Lundqvist C, Johansson B, Berglin E, et al. A randomized double-blind study of epicardial left atrial cryoablation for permanent atrial fibrillation in patients undergoing mitral valve surgery: the SWEDish Multicentre Atrial Fibrillation study (SWEDMAF). Eur Heart J. 2007;28(23):2902-8. [pmid: 17984136].
209 Boersma LV, Castella M, van Boven W, et al. Atrial fibrillation catheter ablation versus surgical ablation treatment (FAST): a 2-center randomized clinical trial. Circulation. 2012;125(1):23-30. [pmid: 22082673].
210 Bulava A, Hanis J, Sitek D, et al. Catheter ablation for paroxysmal atrial fibrillation: a randomized comparison between multielectrode catheter and point-by-point ablation. Pacing Clin Electrophysiol. 2010;33(9):1039-46. [pmid: 20528997].
211 Calo L, Lamberti F, Loricchio ML, et al. Left atrial ablation versus biatrial ablation for persistent and permanent atrial fibrillation: a prospective and randomized study. J Am Coll Cardiol. 2006;47(12):2504-12. [pmid: 16781381].
212 Chevalier P, Leizorovicz A, Maureira P, et al. Left atrial radiofrequency ablation during mitral valve surgery: a prospective randomized multicentre study (SAFIR). Arch Cardiovasc Dis. 2009;102(11):769-75. [pmid: 19944393].
213 Deisenhofer I, Estner H, Reents T, et al. Does electrogram guided substrate ablation add to the success of pulmonary vein isolation in patients with paroxysmal atrial fibrillation? A prospective, randomized study. J Cardiovasc Electrophysiol. 2009;20(5):514-21. [pmid: 19207759].
214 Deneke T, Khargi K, Grewe PH, et al. Efficacy of an additional MAZE procedure using cooled-tip radiofrequency ablation in patients with chronic atrial fibrillation and mitral valve disease. A randomized, prospective trial. Eur Heart J. 2002;23(7):558-66. [pmid: 11922646].
215 Di Biase L, Elayi CS, Fahmy TS, et al. Atrial fibrillation ablation strategies for paroxysmal patients: randomized comparison between different techniques. Circ Arrhythm Electrophysiol. 2009;2(2):113-9. [pmid: 19808455].
216 Dixit S, Marchlinski FE, Lin D, et al. Randomized ablation strategies for the treatment of persistent atrial fibrillation: RASTA study. Circ Arrhythm Electrophysiol. 2012;5(2):287-94. [pmid: 22139886].
217 Dixit S, Gerstenfeld EP, Callans DJ, et al. Comparison of cool tip versus 8-mm tip catheter in achieving electrical isolation of pulmonary veins for long-term control of atrial fibrillation: a prospective randomized pilot study. J Cardiovasc Electrophysiol. 2006;17(10):1074-9. [pmid: 16879626].
218 Dixit S, Gerstenfeld EP, Ratcliffe SJ, et al. Single procedure efficacy of isolating all versus arrhythmogenic pulmonary veins on long-term control of atrial fibrillation: a prospective randomized study. Heart Rhythm. 2008;5(2):174-81. [pmid: 18242535].
219 Doukas G, Samani NJ, Alexiou C, et al. Left atrial radiofrequency ablation during mitral valve surgery for continuous atrial fibrillation: a randomized controlled trial. JAMA. 2005;294(18):2323-9. [pmid: 16278360].
220 Elayi CS, Verma A, Di Biase L, et al. Ablation for longstanding permanent atrial fibrillation: results from a randomized study comparing three different strategies. Heart Rhythm. 2008;5(12):1658-64. [pmid: 19084800].
221 Fiala M, Chovancik J, Nevralova R, et al. Pulmonary vein isolation using segmental versus electroanatomical circumferential ablation for paroxysmal atrial fibrillation: over 3-year results of a prospective randomized study. J Interv Card Electrophysiol. 2008;22(1):13-21. [pmid: 18418704].
222 Forleo GB, Mantica M, De Luca L, et al. Catheter ablation of atrial fibrillation in patients with diabetes mellitus type 2: results from a randomized study comparing pulmonary vein isolation versus antiarrhythmic drug therapy. J Cardiovasc Electrophysiol. 2009;20(1):22-8. [pmid: 18775050].
223 Khaykin Y, Skanes A, Champagne J, et al. A randomized controlled trial of the efficacy and safety of electroanatomic circumferential pulmonary vein ablation supplemented by ablation of complex fractionated atrial electrograms versus potential-guided pulmonary vein antrum isolation guided by intracardiac ultrasound. Circ Arrhythm Electrophysiol. 2009;2(5):481-7. [pmid: 19843915].
224 Le Heuzey JY, De Ferrari GM, Radzik D, et al. A short-term, randomized, double-blind, parallel-group study to evaluate the efficacy and safety of dronedarone versus amiodarone in patients with persistent atrial fibrillation: the DIONYSOS study. J Cardiovasc Electrophysiol. 2010;21(6):597-605. [pmid: 20384650].
225 Oral H, Pappone C, Chugh A, et al. Circumferential pulmonary-vein ablation for chronic atrial fibrillation. N Engl J Med. 2006;354(9):934-41. [pmid: 16510747].
226 Pappone C, Augello G, Sala S, et al. A randomized trial of circumferential pulmonary vein ablation versus antiarrhythmic drug therapy in paroxysmal atrial fibrillation: the APAF Study. J Am Coll Cardiol. 2006;48(11):2340-7. [pmid: 17161267].
227 Pontoppidan J, Nielsen JC, Poulsen SH, et al. Prophylactic cavotricuspid isthmus block during atrial fibrillation ablation in patients without atrial flutter: a randomised controlled trial. Heart. 2009;95(12):994-9. [pmid: 19261602].
228 Wilber DJ, Pappone C, Neuzil P, et al. Comparison of antiarrhythmic drug therapy and radiofrequency catheter ablation in patients with paroxysmal atrial fibrillation: a randomized controlled trial. JAMA. 2010;303(4):333-40. [pmid: 20103757].
229 Roux JF, Zado E, Callans DJ, et al. Antiarrhythmics After Ablation of Atrial Fibrillation (5A Study). Circulation. 2009;120(12):1036-40. [pmid: 19738139].
230 Roy D, Talajic M, Dorian P, et al. Amiodarone to prevent recurrence of atrial fibrillation. Canadian Trial of Atrial Fibrillation Investigators. N Engl J Med. 2000;342(13):913-20. [pmid: 10738049].
231 Srivastava V, Kumar S, Javali S, et al. Efficacy of three different ablative procedures to treat atrial fibrillation in patients with valvular heart disease: a randomised trial. Heart Lung Circ. 2008;17(3):232-40. [pmid: 18242137].
232 Stabile G, Bertaglia E, Senatore G, et al. Catheter ablation treatment in patients with drug-refractory atrial fibrillation: a prospective, multi-centre, randomized, controlled study (Catheter Ablation For The Cure Of Atrial Fibrillation Study). Eur Heart J. 2006;27(2):216-21. [pmid: 16214831].
233 Tamborero D, Mont L, Berruezo A, et al. Left atrial posterior wall isolation does not improve the outcome of circumferential pulmonary vein ablation for atrial fibrillation: a prospective randomized study. Circ Arrhythm Electrophysiol. 2009;2(1):35-40. [pmid: 19808442].
234 Turco P, De Simone A, La Rocca V, et al. Antiarrhythmic drug therapy after radiofrequency catheter ablation in patients with atrial fibrillation. Pacing Clin Electrophysiol. Suppl 1. 2007;30:S112-5. [pmid: 17302684].
235 Van Breugel HN, Nieman FH, Accord RE, et al. A prospective randomized multicenter comparison on health-related quality of life: the value of add-on arrhythmia surgery in patients with paroxysmal, permanent or persistent atrial fibrillation undergoing valvular and/or coronary bypass surgery. J Cardiovasc Electrophysiol. 2010;21(5):511-20. [pmid: 19925605].
236 Verma A, Mantovan R, Macle L, et al. Substrate and Trigger Ablation for Reduction of Atrial Fibrillation (STAR AF): a randomized, multicentre, international trial. Eur Heart J. 2010;31(11):1344-56. [pmid: 20215126].
237 von Oppell UO, Masani N, O'Callaghan P, et al. Mitral valve surgery plus concomitant atrial fibrillation ablation is superior to mitral valve surgery alone with an intensive rhythm control strategy. Eur J Cardiothorac Surg. 2009;35(4):641-50. [pmid: 19233678].
238 Wang J, Meng X, Li H, et al. Prospective randomized comparison of left atrial and biatrial radiofrequency ablation in the treatment of atrial fibrillation. Eur J Cardiothorac Surg. 2009;35(1):116-22. [pmid: 18952450].
239 Willems S, Klemm H, Rostock T, et al. Substrate modification combined with pulmonary vein isolation improves outcome of catheter ablation in patients with persistent atrial fibrillation: a prospective randomized comparison. Eur Heart J. 2006;27(23):2871-8. [pmid: 16782716].
240 Abreu Filho CA, Lisboa LA, Dallan LA, et al. Effectiveness of the maze procedure using cooled-tip radiofrequency ablation in patients with permanent atrial fibrillation and rheumatic mitral valve disease. Circulation. 2005;112(9 Suppl):I20-5. [pmid: 16159816].
241 Anonymous. Maintenance of sinus rhythm in patients with atrial fibrillation: an AFFIRM substudy of the first antiarrhythmic drug. J Am Coll Cardiol. 2003;42(1):20-9. [pmid: 12849654].
242 Akpinar B, Guden M, Sagbas E, et al. Combined radiofrequency modified maze and mitral valve procedure through a port access approach: early and mid-term results. Eur J Cardiothorac Surg. 2003;24(2):223-30. [pmid: 12895612].
243 Albrecht A, Kalil RA, Schuch L, et al. Randomized study of surgical isolation of the pulmonary veins for correction of permanent atrial fibrillation associated with mitral valve disease. J Thorac Cardiovasc Surg. 2009;138(2):454-9. [pmid: 19619795].
244 Arentz T, Weber R, Burkle G, et al. Small or large isolation areas around the pulmonary veins for the treatment of atrial fibrillation? Results from a prospective randomized study. Circulation. 2007;115(24):3057-63. [pmid: 17562956].
245 Bellandi F, Simonetti I, Leoncini M, et al. Long-term efficacy and safety of propafenone and sotalol for the maintenance of sinus rhythm after conversion of recurrent symptomatic atrial fibrillation. Am J Cardiol. 2001;88(6):640-5. [pmid: 11564387].
246 Chen M, Yang B, Chen H, et al. Randomized comparison between pulmonary vein antral isolation versus complex fractionated electrogram ablation for paroxysmal atrial fibrillation. J Cardiovasc Electrophysiol. 2011;22(9):973-81. [pmid: 21539635].
247 Corrado A, Bonso A, Madalosso M, et al. Impact of systematic isolation of superior vena cava in addition to pulmonary vein antrum isolation on the outcome of paroxysmal, persistent, and permanent atrial fibrillation ablation: results from a randomized study. J Cardiovasc Electrophysiol. 2010;21(1):1-5. [pmid: 19732237].
248 de Lima GG, Kalil RA, Leiria TL, et al. Randomized study of surgery for patients with permanent atrial fibrillation as a result of mitral valve disease. Ann Thorac Surg. 2004;77(6):2089-94. discussion 94-5. [pmid: 15172273].
249 De Simone A, De Pasquale M, De Matteis C, et al. VErapamil plus antiarrhythmic drugs reduce atrial fibrillation recurrences after an electrical cardioversion (VEPARAF Study). Eur Heart J. 2003;24(15):1425-9. [pmid: 12909071].
250 Fassini G, Riva S, Chiodelli R, et al. Left mitral isthmus ablation associated with PV Isolation: long-term results of a prospective randomized study. J Cardiovasc Electrophysiol. 2005;16(11):1150-6. [pmid: 16302895].
251 Gaita F, Caponi D, Scaglione M, et al. Long-term clinical results of 2 different ablation strategies in patients with paroxysmal and persistent atrial fibrillation. Circ Arrhythm Electrophysiol. 2008;1(4):269-75. [pmid: 19808418].
252 Gavin AR, Singleton CB, Bowyer J, et al. Pulmonary venous isolation versus additional substrate modification as treatment for paroxysmal atrial fibrillation. J Interv Card Electrophysiol. 2012;33(1):101-7. [pmid: 21938518].
253 Jais P, Cauchemez B, Macle L, et al. Catheter ablation versus antiarrhythmic drugs for atrial fibrillation: the A4 study. Circulation. 2008;118(24):2498-505. [pmid: 19029470].
254 Jessurun ER, van Hemel NM, Defauw JJ, et al. A randomized study of combining maze surgery for atrial fibrillation with mitral valve surgery. J Cardiovasc Surg (Torino). 2003;44(1):9-18. [pmid: 12627066].
255 Katritsis DG, Ellenbogen KA, Panagiotakos DB, et al. Ablation of superior pulmonary veins compared to ablation of all four pulmonary veins. J Cardiovasc Electrophysiol. 2004;15(6):641-5. [pmid: 15175057].
256 Katritsis DG, Panagiotakos DB, Karvouni E, et al. Comparison of effectiveness of carvedilol versus bisoprolol for maintenance of sinus rhythm after cardioversion of persistent atrial fibrillation. Am J Cardiol. 2003;92(9):1116-9. [pmid: 14583369].
257 Kim YH, Lim HE, Pak HN, et al. Role of residual potentials inside circumferential pulmonary veins ablation lines in the recurrence of paroxysmal atrial fibrillation. J Cardiovasc Electrophysiol. 2010;21(9):959-65. [pmid: 20367660].
258 Kochiadakis GE, Igoumenidis NE, Hamilos ME, et al. Sotalol versus propafenone for long-term maintenance of normal sinus rhythm in patients with recurrent symptomatic atrial fibrillation. Am J Cardiol. 2004;94(12):1563-6. [pmid: 15589019].
259 Kochiadakis GE, Igoumenidis NE, Hamilos MI, et al. Long-term maintenance of normal sinus rhythm in patients with current symptomatic atrial fibrillation: amiodarone vs propafenone, both in low doses. Chest. 2004;125(2):377-83. [pmid: 14769712].
260 Kochiadakis GE, Igoumenidis NE, Marketou ME, et al. Low dose amiodarone and sotalol in the treatment of recurrent, symptomatic atrial fibrillation: a comparative, placebo controlled study. Heart. 2000;84(3):251-7. [pmid: 10956284].
261 Kochiadakis GE, Marketou ME, Igoumenidis NE, et al. Amiodarone, sotalol, or propafenone in atrial fibrillation: which is preferred to maintain normal sinus rhythm?. Pacing Clin Electrophysiol. 2000;23(11 Pt 2):1883-7. [pmid: 11139949].
262 Krittayaphong R, Raungrattanaamporn O, Bhuripanyo K, et al. A randomized clinical trial of the efficacy of radiofrequency catheter ablation and amiodarone in the treatment of symptomatic atrial fibrillation. J Med Assoc Thai. Suppl 1. 2003;86:S8-16. [pmid: 12866763].
263 Liu X, Tan HW, Wang XH, et al. Efficacy of catheter ablation and surgical CryoMaze procedure in patients with long-lasting persistent atrial fibrillation and rheumatic heart disease: a randomized trial. Eur Heart J. 2010;31(21):2633-41. [pmid: 20573636].
264 Liu X, Long D, Dong J, et al. Is circumferential pulmonary vein isolation preferable to stepwise segmental pulmonary vein isolation for patients with paroxysmal atrial fibrillation?. Circ J. 2006;70(11):1392-7. [pmid: 17062959].
265 Nilsson B, Chen X, Pehrson S, et al. Recurrence of pulmonary vein conduction and atrial fibrillation after pulmonary vein isolation for atrial fibrillation: a randomized trial of the ostial versus the extraostial ablation strategy. Am Heart J. 2006;152(3):537 e1-8. [pmid: 16923426].
266 Oral H, Chugh A, Good E, et al. Randomized comparison of encircling and nonencircling left atrial ablation for chronic atrial fibrillation. Heart Rhythm. 2005;2(11):1165-72. [pmid: 16253904].
267 Oral H, Chugh A, Lemola K, et al. Noninducibility of atrial fibrillation as an end point of left atrial circumferential ablation for paroxysmal atrial fibrillation: a randomized study. Circulation. 2004;110(18):2797-801. [pmid: 15505091].
268 Pires LM, Leiria TL, de Lima GG, et al. Comparison of surgical cut and sew versus radiofrequency pulmonary veins isolation for chronic permanent atrial fibrillation: a randomized study. Pacing Clin Electrophysiol. 2010;33(10):1249-57. [pmid: 20546155].
269 Plewan A, Lehmann G, Ndrepepa G, et al. Maintenance of sinus rhythm after electrical cardioversion of persistent atrial fibrillation; sotalol vs bisoprolol. Eur Heart J. 2001;22(16):1504-10. [pmid: 11482924].
270 Schuetz A, Schulze CJ, Sarvanakis KK, et al. Surgical treatment of permanent atrial fibrillation using microwave energy ablation: a prospective randomized clinical trial. Eur J Cardiothorac Surg. 2003;24(4):475-80. discussion 80. [pmid: 14500062].
271 Sheikh I, Krum D, Cooley R, et al. Pulmonary vein isolation and linear lesions in atrial fibrillation ablation. J Interv Card Electrophysiol. 2006;17(2):103-9. [pmid: 17318445].
272 Wazni O, Marrouche NF, Martin DO, et al. Randomized study comparing combined pulmonary vein-left atrial junction disconnection and cavotricuspid isthmus ablation versus pulmonary vein-left atrial junction disconnection alone in patients presenting with typical atrial flutter and atrial fibrillation. Circulation. 2003;108(20):2479-83. [pmid: 14610012].
273 Wazni OM, Marrouche NF, Martin DO, et al. Radiofrequency ablation vs antiarrhythmic drugs as first-line treatment of symptomatic atrial fibrillation: a randomized trial. JAMA. 2005;293(21):2634-40. [pmid: 15928285].
274 Knaut M, Kolberg S, Brose S, et al. Epicardial microwave ablation of permanent atrial fibrillation during a coronary bypass and/or aortic valve operation: Prospective, randomised, controlled, mono-centric study. Appl Cardiopulm Pathophysiol. 2010;14(4):220-8.
275 Karch MR, Zrenner B, Deisenhofer I, et al. Freedom from atrial tachyarrhythmias after catheter ablation of atrial fibrillation: a randomized comparison between 2 current ablation strategies. Circulation. 2005;111(22):2875-80. [pmid: 15927974].
276 Oral H, Chugh A, Yoshida K, et al. A randomized assessment of the incremental role of ablation of complex fractionated atrial electrograms after antral pulmonary vein isolation for long-lasting persistent atrial fibrillation. J Am Coll Cardiol. 2009;53(9):782-9. [pmid: 19245970].
277 Oral H, Chugh A, Good E, et al. Randomized evaluation of right atrial ablation after left atrial ablation of complex fractionated atrial electrograms for long-lasting persistent atrial fibrillation. Circ Arrhythm Electrophysiol. 2008;1(1):6-13. [pmid: 19808388].
278 Mun HS, Joung B, Shim J, et al. Does additional linear ablation after circumferential pulmonary vein isolation improve clinical outcome in patients with paroxysmal atrial fibrillation? Prospective randomised study. Heart. 2012;98(6):480-4. [pmid: 22285969].
279 Sawhney N, Anousheh R, Chen W, et al. Circumferential pulmonary vein ablation with additional linear ablation results in an increased incidence of left atrial flutter compared with segmental pulmonary vein isolation as an initial approach to ablation of paroxysmal atrial fibrillation. Circ Arrhythm Electrophysiol. 2010;3(3):243-8. [pmid: 20339034].
280 Hocini M, Jais P, Sanders P, et al. Techniques, evaluation, and consequences of linear block at the left atrial roof in paroxysmal atrial fibrillation: a prospective randomized study. Circulation. 2005;112(24):3688-96. [pmid: 16344401].
281 Bertaglia E, D'Este D, Zerbo F, et al. Success of serial external electrical cardioversion of persistent atrial fibrillation in maintaining sinus rhythm; a randomized study. Eur Heart J. 2002;23(19):1522-8. [pmid: 12242072].
282 Haissaguerre M, Sanders P, Hocini M, et al. Changes in atrial fibrillation cycle length and inducibility during catheter ablation and their relation to outcome. Circulation. 2004;109(24):3007-13. [pmid: 15184286].
283 Wang XH, Liu X, Sun YM, et al. Pulmonary vein isolation combined with superior vena cava isolation for atrial fibrillation ablation: a prospective randomized study. Europace. 2008;10(5):600-5. [pmid: 18442966].
284 Atwood JE, Myers JN, Tang XC, et al. Exercise capacity in atrial fibrillation: a substudy of the Sotalol-Amiodarone Atrial Fibrillation Efficacy Trial (SAFE-T). Am Heart J. 2007;153(4):566-72. [pmid: 17383295].
285 Batcher EL, Tang XC, Singh BN, et al. Thyroid function abnormalities during amiodarone therapy for persistent atrial fibrillation. Am J Med. 2007;120(10):880-5. [pmid: 17904459].
286 Singh SN, Tang XC, Reda D, et al. Systematic electrocardioversion for atrial fibrillation and role of antiarrhythmic drugs: a substudy of the SAFE-T trial. Heart Rhythm. 2009;6(2):152-5. [pmid: 19187902].
287 Dorian P, Mangat I. Quality of life variables in the selection of rate versus rhythm control in patients with atrial fibrillation: observations from the Canadian Trial of Atrial Fibrillation. Card Electrophysiol Rev. 2003;7(3):276-9. [pmid: 14739727].
288 Dorian P, Paquette M, Newman D, et al. Quality of life improves with treatment in the Canadian Trial of Atrial Fibrillation. Am Heart J. 2002;143(6):984-90. [pmid: 12075253].
289 Lumer GB, Roy D, Talajic M, et al. Amiodarone reduces procedures and costs related to atrial fibrillation in a controlled clinical trial. Eur Heart J. 2002;23(13):1050-6. [pmid: 12093058].
290 Khargi K, Deneke T, Haardt H, et al. Saline-irrigated, cooled-tip radiofrequency ablation is an effective technique to perform the maze procedure. Ann Thorac Surg. 2001;72(3):S1090-5. [pmid: 11570381].
291 Leong-Sit P, Roux JF, Zado E, et al. Antiarrhythmics after ablation of atrial fibrillation (5A Study): six-month follow-up study. Circ Arrhythm Electrophysiol. 2011;4(1):11-4. [pmid: 21076158].
292 Pappone C, Vicedomini G, Giuseppe A, et al. Radiofrequency Catheter Ablation and Antiarrhythmic Drug Therapy: A Prospective, Randomized 4-Year Follow-Up Trial - The APAF Study. Circ Arrhythm Electrophysiol. 2011. [pmid: 21946315].
293 Reynolds MR, Walczak J, White SA, et al. Improvements in symptoms and quality of life in patients with paroxysmal atrial fibrillation treated with radiofrequency catheter ablation versus antiarrhythmic drugs. Circ Cardiovasc Qual Outcomes. 2010;3(6):615-23. [pmid: 20940250].
294 Antzelevitch C, Burashnikov A. Atrial-selective sodium channel block as a novel strategy for the management of atrial fibrillation. Ann N Y Acad Sci. 2010;1188:78-86. [pmid: 20201889].
295 Brignole M, Menozzi C, Gasparini M, et al. An evaluation of the strategy of maintenance of sinus rhythm by antiarrhythmic drug therapy after ablation and pacing therapy in patients with paroxysmal atrial fibrillation. Eur Heart J. 2002;23(11):892-900. [pmid: 12042011].
296 Carlsson J, Miketic S, Windeler J, et al. Randomized trial of rate-control versus rhythm-control in persistent atrial fibrillation: the Strategies of Treatment of Atrial Fibrillation (STAF) study. J Am Coll Cardiol. 2003;41(10):1690-6. [pmid: 12767648].
297 Hohnloser SH, Kuck KH, Lilienthal J. Rhythm or rate control in atrial fibrillation—Pharmacological Intervention in Atrial Fibrillation (PIAF): a randomised trial. Lancet. 2000;356(9244):1789-94. [pmid: 11117910].
298 Okcun B, Yigit Z, Arat A, et al. Comparison of rate and rhythm control in patients with atrial fibrillation and nonischemic heart failure. Jpn Heart J. 2004;45(4):591-601. [pmid: 15353870].
299 Opolski G, Torbicki A, Kosior DA, et al. Rate control vs rhythm control in patients with nonvalvular persistent atrial fibrillation: the results of the Polish How to Treat Chronic Atrial Fibrillation (HOT CAFE) Study. Chest. 2004;126(2):476-86. [pmid: 15302734].
300 Shelton RJ, Clark AL, Goode K, et al. A randomised, controlled study of rate versus rhythm control in patients with chronic atrial fibrillation and heart failure: (CAFE-II Study). Heart. 2009;95(11):924-30. [pmid: 19282313].
301 Talajic M, Khairy P, Levesque S, et al. Maintenance of sinus rhythm and survival in patients with heart failure and atrial fibrillation. J Am Coll Cardiol. 2010;55(17):1796-802. [pmid: 20413028].
302 Vora A, Karnad D, Goyal V, et al. Control of heart rate versus rhythm in rheumatic atrial fibrillation: a randomized study. J Cardiovasc Pharmacol Ther. 2004;9(2):65-73. [pmid: 15309242].
303 Yildiz A, Yigit Z, Okcun B, et al. Comparison of rate and rhythm control in hypertension patients with atrial fibrillation. Circ J. 2008;72(5):705-8. [pmid: 18441447].
304 Khan MN, Jais P, Cummings J, et al. Pulmonary-vein isolation for atrial fibrillation in patients with heart failure. N Engl J Med. 2008;359(17):1778-85. [pmid: 18946063].
305 MacDonald MR, Connelly DT, Hawkins NM, et al. Radiofrequency ablation for persistent atrial fibrillation in patients with advanced heart failure and severe left ventricular systolic dysfunction: a randomised controlled trial. Heart. 2011;97(9):740-7. [pmid: 21051458].
306 Cosedis Nielsen J, Johannessen A, Raatikainen P, et al. Radiofrequency ablation as initial therapy in paroxysmal atrial fibrillation. N Engl J Med. 2012;367(17):1587-95. [pmid: 23094720].
307 Verma A, Champagne J, Sapp J, et al. Discerning the incidence of symptomatic and asymptomatic episodes of atrial fibrillation before and after catheter ablation (DISCERN AF): a prospective, multicenter study. JAMA Internal Medicine. 2013;173(2):149-56. [pmid: 23266597].
308 Robinson KA, Saldanha IJ, Mckoy NA. Frameworks for Determining Research Gaps During Systematic Reviews. Methods Future Research Needs Report No. 2. (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. HHSA 290-2007-10061-I.) AHRQ Publication No. 11-EHC043-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2011. www.effectivehealthcare.ahrq.gov/reports/final.cfm.