# Methods

The methods for this comparative effectiveness review (CER) follow those suggested in the Agency for Healthcare Research and Quality (AHRQ) Methods Guide for Effectiveness and Comparative Effectiveness Reviews (hereafter referred to as the Methods Guide).22 The main sections in this chapter reflect the elements of the protocol established for the CER; certain methods map to the Preferred Reporting Items for Systematic Reviews and Meta-Analyses (PRISMA) checklist.23

## Topic Refinement and Review Protocol

During the topic refinement stage, we solicited input from Key Informants representing medical professional societies/clinicians in the areas of general internal medicine, geriatrics, cardiology, electrophysiology, and primary care; patients; scientific experts; Federal agencies; and payers to help define the Key Questions (KQs). The KQs were then posted for public comment for 4 weeks from September 27 to October 25, 2011, and the comments received were considered in the development of the research protocol. We next convened a Technical Expert Panel (TEP) comprising clinical, content, and methodological experts to provide input to the draft protocol in defining populations, interventions, comparisons, and outcomes, and in identifying particular studies or databases to search.24 Before involvement in the CER process, the Key Informants and members of the TEP were required to disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts. Any potential conflicts of interest were balanced or mitigated. Neither Key Informants nor members of the TEP performed analysis of any kind, nor did any of them contribute to the writing of this report.

## Literature Search Strategy

### Search Strategy

To identify relevant published literature, we searched PubMed^®^, Embase^®^, and the Cochrane Database of Systematic Reviews (CDSR), limiting the search to studies published from January 1, 2000, to August 1, 2012. We believe that the evidence published from 2000 on represents the current standard of care for patients with atrial fibrillation (AF) and relevant comorbidities. In addition, a 2001 AHRQ report on the management of new onset AF summarized the evidence prior to 2000.^25-27^ Where possible, we used existing validated search filters (such as the Clinical Queries Filters in PubMed). An experienced search librarian guided all searches. Exact search strings are included in Appendix A. We supplemented the electronic searches with a manual search of citations from a set of key primary and systematic review articles.16,19,25-135 We also considered studies identified through suggestions from external peer and public reviewers. Final updating of all database searches was performed during the review period. All citations were imported into an electronic database (EndNote^®^ X4; Thomson Reuters, Philadelphia, PA).

We used several approaches to identify relevant grey literature including requests to drug and device manufacturers for scientific information packets and searches of study registries and conference abstracts for relevant articles from completed studies. Grey literature databases searched included ClinicalTrials.gov (final search date August 17, 2012); the World Health Organization (WHO) International Clinical Trials Registry Platform (ICTRP) search portal (final search date August 17, 2012); and ProQuest COS Conference Papers Index (final search date August 1, 2012). Search terms used for all of the above sources are provided in Appendix A.

### Inclusion and Exclusion Criteria

The PICOTS (Populations, Interventions, Comparators, Outcomes, Timings, and Settings of interest) criteria used to screen articles for inclusion/exclusion at both the title-and-abstract and full-text screening stages are detailed in Table 1.

Table 1 Inclusion and exclusion criteria

PICOTS Element | Inclusion Criteria | Exclusion Criteria
Populations | - Humans; - Adults (age ≥ 18 years of age); - Patients with AF (includes atrial flutter); ○ Paroxysmal AF (recurrent episodes that self-terminate in less than 7 days); ○ Persistent AF (recurrent episodes that last more than 7 days); ○ Permanent AF (an ongoing, long-term episode); - Subgroups of potential interest include:; ○ Patients stratified by age (≤ 40, 41–64, 65–74, 75–84, 85+); ○ Patients with different types of AF (paroxysmal, persistent, permanent); ○ Patients with specific comorbidities (heart failure, coronary artery disease, kidney disease, hypertrophic cardiomyopathy, thyroid disease, pulmonary disease); ○ Patients for whom a prior rate- (KQ 3) or rhythm-control (KQ 5) pharmacological strategy was ineffective; ○ Women; ○ Patients with an enlarged left atrium; ○ Patients at high risk for stroke and bleeding events (patients with diabetes, heart failure, and hypertension) | - Patients who have known reversible causes of AF (including but not limited to postoperative, postmyocardial infarction, hyperthyroidism); - All subjects are <18 years of age, or some subjects are under <18 years of age but results are not broken down by age
Interventions | - Pharmacological agents for rate control (KQ 1, KQ 2, KQ 3, KQ 6):; ○ Beta blockers (e.g., acebutolol, atenolol, bisoprolol, carvedilol, esmolol [acute rate lowering only], metoprolol, nadalol, nebivolol, timolol); ○ Non-dihydropyridine calcium channel blockers (verapamil, diltiazem); ○ Other (digoxin, amiodarone, dronedarone); - Procedures for rate control (KQ 3, KQ 6); ○ AVN ablation and permanent pacemaker implantation; - Pharmacological agents for rhythm control (KQ 4, KQ 5, KQ 6):; ○ Amiodarone; ○ Disopyramide; ○ Dofetilide; ○ Dronedarone; ○ Flecainide; ○ Ibutilide (acute conversion only); ○ Propafenone; ○ Sotalol; ○ Beta blockers (e.g., acebutolol, atenolol, bisoprolol, carvedilol, esmolol [acute rate lowering only], metoprolol, nadalol, nebivolol, timolol); ○ Calcium channel blockers (verapamil, diltiazem); - Procedures for rhythm control (KQ 5, KQ 6); ○ Electrical cardioversion; ○ AF ablation by pulmonary vein isolation; ■ Open surgical procedures; ■ Minimally invasive procedures; ■ Transcatheter procedures; ○ Surgical Maze procedure; ○ Cardiac resynchronization therapy | - Studies comparing different imaging or mapping techniques (focus is on comparisons between treatment strategies); - Studies of intracardiac echocardiography, different ablation sources and energies, different techniques of septal puncture, and different diagnostic maneuvers during an ablation procedure; - Studies of atrial flutter ablation, ablation for post-pulmonary vein isolation tachycardias including atrial flutter, and studies of internal cardioversion, transesophageal cardioversion and patient-enabled cardioversion using an ICD; - Studies investigating use of antiarrhythmic drugs periablation or after failed pulmonary vein isolation; - Studies of any intervention not available in the U.S., including intravenous formulations of medications that are available in the U.S. only in an oral form; - Studies with a majority of patients taking an antiarrhythmic drug not specified as an intervention of interest, unless the study includes a comparison between a drug of interest and a control arm
Comparators | - KQ 1: Other rate-control pharmacological agents of interest; - KQ 2: Other strict/lenient rate-control strategies of interest; - KQ 3: Other procedural, nonpharmacological, and other specific pharmacological rate-control therapies of interest; - KQ 4: Other antiarrhythmic agents of interest; - KQ 5: Other procedural, nonpharmacological, and other specific pharmacological rhythm-control therapies of interest; - KQ 6: Other rhythm-control or rate-control therapies of interest | None
Outcomes | Study assesses a patient-centered outcome of interest:; - Intermediate outcomes:; ○ Restoration of sinus rhythm (conversion); ○ Maintenance of sinus rhythm; ○ Recurrence of AF at 12 months; ○ Ventricular rate control; ○ Development of cardiomyopathy; - Final outcomes:^a^; ○ Mortality (all-cause, cardiovascular); ○ Myocardial infarction; ○ Cardiovascular hospitalizations (including AF hospitalizations); ○ Heart failure symptoms; ○ Control of AF symptoms (e.g., palpitations, exercise capacity); ○ Quality of life; ○ Functional status; ○ Stroke and other embolic events; ○ Bleeding events; - Adverse events:; ○ Adverse events from drug therapies (e.g., hypotension, hypothyroidism and hyperthyroidism, arrhythmias [bradyarrhythmias, tachyarrhythmias, or proarrhythmias], allergic reactions, hepatotoxicity, neurotoxicity, pulmonary toxicity, ophthalmological toxicity, dermatological toxicity); ○ Procedural complications (including pulmonary vein stenosis, left atrial esophageal fistula, and phrenic nerve palsy) | Study does not include any outcomes of interest
Timings | - Timing of followup not limited | None
Settings | - Inpatient and outpatient | None
Study designs | - Original data; - KQ 1: RCTs (≥ 20 patients); - KQ 2: RCTs (≥ 20 patients) and prospective and retrospective observational studies or registries (≥ 100 patients); - KQ 3: RCTs (≥ 20 patients); - KQ 4: RCTs (≥ 20 patients); - KQ 5: RCTs (≥ 20 patients) and (for studies related to CRT) prospective and retrospective observational studies or registries (≥ 100 patients); - KQ 6: RCTs (≥ 20 patients) | - Not a clinical study (e.g., editorial, nonsystematic review, letter to the editor, case series)
Publications | - English-language publications only; - Relevant systematic reviews, meta-analyses, or methods articles (used for background only)^b^; - Published on or after January 1, 2000 | - Non-English-language publications^c^

a Final outcomes are direct health outcomes that a patient experiences or feels.

b Systematic reviews and meta-analyses were excluded from direct abstraction; those representing key sources were hand-searched as potential sources of additional citations to consider in the review. Articles providing methods information only (i.e., not reporting data) were not considered among the formal set of included articles, but were used to supplement the abstractions of the studies they referenced.

c Given the high volume of literature available in English-language publications (including the majority of known important studies), and concerns about the applicability of non-English publication studies to settings in the United States, non-English articles were excluded.

Abbreviations: AF=atrial fibrillation; AVN=atrioventricular node; CRT=cardiac resynchronization therapy; KQ=Key Question; ICD=implantable cardioverter defibrillator; PICOTS=Populations, Interventions, Comparators, Outcomes, Timing, Settings; RCTs=randomized controlled trials

### Study Selection

Using the prespecified inclusion and exclusion criteria described in Table 1, two investigators independently reviewed titles and abstracts for potential relevance to the KQs. Articles included by either reviewer underwent full-text screening. At the full-text review stage, paired researchers independently reviewed the articles and indicated a decision to “include” or “exclude” the article for data abstraction. When the two reviewers arrived at different decisions about whether to include or exclude an article, they reconciled the difference through review and discussion, or through a third-party arbitrator if needed. Full-text articles meeting our eligibility criteria were included for data abstraction. Relevant systematic review articles, meta-analyses, and methods articles were flagged for manual searching of references and cross-referencing against the library of citations identified through electronic database searching.

For citations retrieved by searching the grey literature, the above-described procedures were modified such that a single screener initially reviewed all search results; final eligibility of citations for data abstraction was determined by duplicate screening review. All screening decisions were made and tracked in a Distiller SR database (Evidence Partners Inc., Manotick, ON, Canada).

### Data Extraction

The research team created data abstraction forms and evidence table templates for abstracting data for each KQ. Based on clinical and methodological expertise, a pair of investigators was assigned to abstract data from each eligible article. One investigator abstracted the data, and the second reviewed the completed abstraction form alongside the original article to check for accuracy and completeness. Disagreements were resolved by consensus, or by obtaining a third reviewer's opinion if consensus could not be reached. To aid in both reproducibility and standardization of data collection, researchers received data abstraction instructions directly on each form created specifically for this project within the DistillerSR database.

We designed the data abstraction forms to collect the data required to evaluate the specified eligibility criteria for inclusion in this review, as well as demographic and other data needed for determining outcomes (intermediate, final, and adverse events outcomes). We paid particular attention to describing the details of treatment (e.g., pharmacotherapy dosing, methods of procedural therapies), patient characteristics (e.g., etiology of AF), and study design (e.g., randomized controlled trial [RCT] versus observational) that may be related to outcomes. In addition, we described comparators carefully, as treatment standards may have changed during the period covered by this review. The safety outcomes were framed to help identify adverse events, including those from drug therapies (e.g., hypotension; hypothyroidism and hyperthyroidism; arrhythmias [bradyarrhythmias, tachyarrhythmias, or proarrhythmias]; allergic reactions; hepatotoxicity; neurotoxicity; pulmonary toxicity) and those resulting from procedural complications. Data necessary for assessing quality and applicability, as described in the Methods Guide,22 were abstracted. Before the data abstraction form templates were used, they were pilot-tested with a sample of included articles to ensure that all relevant data elements were captured and that there was consistency/reproducibility between abstractors. Forms were revised as necessary before full abstraction of all included articles. Some outcomes were reported only in figures. In these instances, we used the web-based software, EnGauge Digitizer (http://digitizer.sourceforge.net/) to convert graphical displays to numerical data. Appendix B provides a detailed listing of the elements included in the data abstraction forms.

## Quality (Risk of Bias) Assessment of Individual Studies

We evaluated the quality of individual studies using the approach described in the Methods Guide.22 To assess quality, we used the strategy to (1) classify the study design, (2) apply predefined criteria for quality and critical appraisal, and (3) arrive at a summary judgment of the study's quality. We applied criteria for each study type derived from core elements described in the Methods Guide. Criteria of interest for all studies included similarity of groups at baseline, extent to which outcomes were described, blinding of subjects and providers, blinded assessment of the outcome(s), intention-to-treat analysis, and differential loss to followup between the compared groups or overall high loss to followup. Criteria specific to RCTs included methods of randomization and allocation concealment. For observational studies, additional elements such as methods for selection of participants, measurement of interventions/exposures, addressing any design-specific issues, and controlling for confounding were considered. To indicate the summary judgment of the quality of individual studies, we used the summary ratings of good, fair, or poor based on the classification scheme presented in Table 2.

Table 2 Definitions of overall quality ratings

Quality Rating | Description
Good | A study with the least bias; results are considered valid. A good study has a clear description of the population, setting, interventions, and comparison groups; uses a valid approach to allocate patients to alternative treatments; has a low dropout rate; and uses appropriate means to prevent bias, measure outcomes, and analyze and report results.
Fair | A study that is susceptible to some bias but probably not enough to invalidate the results. The study may be missing information, making it difficult to assess limitations and potential problems. As the fair-quality category is broad, studies with this rating vary in their strengths and weaknesses. The results of some fair-quality studies are possibly valid, while others are probably valid.
Poor | A study with significant bias that may invalidate the results. These studies have serious errors in design, analysis, or reporting; have large amounts of missing information; or have discrepancies in reporting. The results of a poor-quality study are at least as likely to reflect flaws in the study design as to indicate true differences between the compared interventions.

Studies of different designs were graded within the context of their respective designs. Thus, RCTs were graded good, fair, or poor, and observational studies were separately graded good, fair, or poor.

## Data Synthesis

We began our data synthesis by summarizing key features of the included studies for each KQ: patient characteristics; clinical settings; interventions; and intermediate, final, and adverse event outcomes.

We grouped interventions by drug class; in this context, we considered all nondihydropyridine calcium channel blocker drugs to be similar enough to be grouped together and all beta blocker drugs to be similar enough to be grouped together. Similarly, we categorized procedures into electrical cardioversion, atrioventricular node (AVN) ablation, AF ablation by pulmonary vein isolation (either open surgical, minimally invasive, or transcatheter procedures), and surgical Maze procedures, and explored comparisons among these categories. For the KQs focusing on pharmacological agents versus procedures (KQ 3 and KQ 5), we also explored grouping all pharmacological agents together and comparing them to all procedures. Finally for our evaluation of rate- versus rhythm-control strategies (KQ 6), we grouped all rate-control strategies together and all rhythm-control strategies together regardless of the specific agent or procedure.

We determined the appropriateness of a quantitative synthesis (i.e., meta-analysis) based on the volume of relevant literature, conceptual homogeneity of the studies in terms of study population and outcomes, and completeness of the reporting of results. Where at least three comparable studies reported the same outcome, we used random-effects models to synthesize the available evidence quantitatively using Comprehensive Meta-Analysis software (Version 2; Biostat, Englewood, NJ). We tested for heterogeneity using graphical displays and test statistics (Q and I^2^ statistics), while recognizing that the ability of statistical methods to detect heterogeneity may be limited. For comparison, we also performed fixed-effect meta-analyses. We present summary estimates, standard errors, and confidence intervals in our data synthesis. Unless noted otherwise, when we were able to calculate odds ratios (ORs), we assumed that an OR between 0.9 and 1.1, with a confidence interval that also crossed 1.0, suggested that there was no clinically significant difference between treatment strategies; in such cases, we describe the treatment strategies being compared as having “comparable efficacy.” For some outcomes, study quality or other factors affected comparability; these exceptions are explained on a case-by-case basis.

We anticipated that intervention effects might be heterogeneous. We hypothesized that the methodological quality of individual studies, study type, the characteristics of the comparator, and patients' underlying clinical presentation would be associated with the intervention effects. Where there were sufficient studies, we performed subgroup analyses and/or meta-regression analyses to examine these hypotheses.

## Strength of the Body of Evidence

We rated the strength of evidence for each KQ and outcome using the approach described in the Methods Guide.22,136 In brief, the approach requires assessment of four domains: risk of bias, consistency, directness, and precision (Table 3).

Table 3 Strength of evidence—required domains

Domain | Rating | How Assessed
Risk of bias | Low Medium High | Assessed primarily through study design (RCT versus observational study) and aggregate study quality
Consistency | Consistent Inconsistent Unknown/not applicable | Assessed primarily through whether effect sizes are generally on the same side of “no effect” and the overall range of effect sizes
Directness | Direct Indirect | Assessed by whether the evidence involves direct comparisons or indirect comparisons through use of surrogate outcomes or use of separate bodies of evidence
Precision | Precise Imprecise | Based primarily on the size of the confidence intervals of effect estimates

Abbreviation: RCT=randomized controlled trial

Additional domains were used when appropriate: strength of association (magnitude of effect) and publication bias (as assessed through a search of ClinicalTrials.gov). These domains were considered qualitatively, and a summary rating of “high,” “moderate,” or “low” strength of evidence was assigned after discussion by two reviewers. In some cases, high, moderate, or low ratings were impossible or imprudent to make; for example, when no evidence was available or when evidence on the outcome was too weak, sparse, or inconsistent to permit any conclusion to be drawn. In these situations, a grade of “insufficient” was assigned. This four-level rating scale consists of the following definitions:

- High—High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
- Moderate—Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
- Low—Low confidence that the evidence reflects the true effect. Further research is likely to change the confidence in the estimate of effect and is likely to change the estimate.
- Insufficient—Evidence either is unavailable or does not permit estimation of an effect.

## Applicability

We assessed applicability across the KQs using the method described in the Methods Guide.22,137 In brief, we used the PICOTS format to organize information relevant to applicability. The most important applicability issue is whether the outcomes observed in any individual study, with its specific patient population and method of implementing treatments, can confidently be extrapolated to a broader context. Differences in study population characteristics (e.g., age, comorbidities) or methods of implementing interventions can affect the rates of events observed in both control and intervention groups and may limit the generalizability of the findings. Specific criteria considered in applicability assessments are listed in Appendix B. We used these data to evaluate the applicability to clinical practice, paying special attention to study eligibility criteria, demographic features of the enrolled population in comparison to the target population, characteristics of the intervention used in comparison with care models currently in use, the possibility of surgical learning curves, and clinical relevance and timing of the outcome measures. We summarized issues of applicability qualitatively.

## Peer Review and Public Commentary

Nominations for peer reviewers were solicited from several sources, including the TEP and interested Federal agencies. Experts in general cardiology, heart failure, electrophysiology, ablation, cardioversion, cardiac resynchronization therapy (CRT), cardiothoracic surgery, pharmacological treatments for AF, geriatrics, health services research, and primary care, along with individuals representing stakeholder and user communities, were invited to provide external peer review of the draft report. AHRQ, an associate editor, and members of the TEP also provided comments. In addition, the draft report was posted on AHRQ's Web site for public comment for 4 weeks, from July 27, 2012, to August 24, 2012. We have addressed all reviewer comments, revising the text as appropriate, and have documented our responses in a disposition of comments report that will be made available 3 months after the Agency posts the final report on AHRQ's Web site. A list of peer reviewers submitting comments on the draft report is provided in the front matter of this report.