# Peer Reviewers

Prior to publication of the final report, the EPC sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual peer reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Wilbert S. Aronow, M.D.
  Professor of Medicine
  New York Medical College
  Valhalla, NY
- Paul Heidenreich, M.D.
  Professor of Cardiovascular Medicine
  Stanford University
  Stanford, CA
- Richard L. Page, M.D.
  Chair, Department of Medicine
  University of Wisconsin
  Madison, WI
- James E. Tisdale, Pharm.D.
  Professor of Pharmacy Practice
  Purdue University
  Indianapolis, IN