# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Hussein Rashid Al-Khalidi, Ph.D.
  Associate Professor of Biostatistics and Bioinformatics
  Duke University
  Durham, NC
- G. Hossein Almassi, M.D.
  Professor of Cardiothoracic Surgery
  Medical College of Wisconsin
  Milwaukee, WI
- Javed Butler, M.P.H., M.D.
  Director, Heart Failure Research
  Professor of Medicine
  Emory University
  Atlanta, GA
- Roger Chou, M.D.
  Oregon Health & Science University
  Portland, OR
- Paul Dorian, M.D., M.Sc.
  Professor of Pharmacology
  Director, Division of Cardiology
  University of Toronto
  Toronto, Ontario, Canada
- Michael L. LeFevre, M.D., M.S.P.H.
  Professor and Vice Chair of Future of Family Medicine
  University of Missouri
  Columbia, MO
- Debjani Mukherjee, M.P.H.
  Associate Director, Evidence-Based Medicine
  American College of Cardiology
  Washington, DC
- Eric N. Prystowsky, M.D.
  Director of the Clinical Electrophysiology Laboratory
  St. Vincent Medical Group
  Indianapolis, IN
- Michael W. Rich, M.D.
  Professor of Cardiology
  Washington University
  St. Louis, MO
- Paul D. Varosy, M.D.
  Director of Cardiac Electrophysiology
  VA Eastern Colorado Health Care System
  Denver, CO