# Discussion

## Key Findings and Strength of Evidence

In this comparative effectiveness review (CER), we reviewed 148 studies represented by 182 publications and involving 25,524 patients that directly compared rate- and rhythm-control strategies in patients with atrial fibrillation (AF).

### KQ 1 Rate-Control Drugs

Our review of rate-control drugs explored the comparative effectiveness of beta blockers, calcium channel blockers, digoxin, and other antiarrhythmics in controlling ventricular rate. The 14 included studies varied in terms of the drugs involved, and the lack of multiple studies exploring similar comparisons decreased our ability to quantitatively synthesize their findings. Our findings highlight the lack of definitive data on the superiority of one beta blocker over another or against calcium channel blockers. Our findings underscore the importance of conducting studies comparing the effectiveness, tolerability and safety of different beta blockers and calcium channel blockers and in different patient populations.

Table 23 summarizes the strength of evidence for the most commonly used classes of therapies and evaluated outcomes. Details about the specific components of these ratings (risk of bias, consistency, directness, and precision) are available in the Results chapter. For ventricular rate control, most comparisons were evaluated in one small study, resulting in insufficient evidence to support conclusions about comparative effectiveness. Exceptions were as follows: There was low strength of evidence that amiodarone was comparable to the calcium channel blocker diltiazem, and that amiodarone controlled ventricular rate better than digoxin, and there was high strength of evidence for a consistent benefit of verapamil or diltiazem compared with digoxin for rate control. There was insufficient evidence regarding the effect of rate-control therapies on quality of life.

Table 23 Summary of strength of evidence and effect estimate for KQ 1

Treatment Comparison | Ventricular Rate Control | Quality of Life
Beta Blockers vs. Digoxin | SOE=Insufficient (1 study, 47 patients) | SOE=Insufficient (No studies)
Beta Blockers vs. Calcium Channel Blockers | SOE=Insufficient (1 study, 40 patients) | SOE=Insufficient (No studies)
Beta Blockers vs. Calcium Channel Blockers in Patients Taking Digoxin | SOE=Insufficient (1 study, 29 patients) | SOE=Insufficient (1 study, 29 patients)
Sotalol vs. Metoprolol in Patients Taking Digoxin | SOE=Insufficient (1 study, 23 patients) | SOE=Insufficient (No studies)
Amiodarone vs. Calcium Channel Blockers | SOE=Low (3 studies, 271 patients) Amiodarone is comparable to the calcium channel blocker diltiazem for rate control | SOE=Insufficient (No studies)
Amiodarone vs. Digoxin | SOE=Low (3 studies, 390 patients) Amiodarone controlled ventricular rate better than digoxin across 2 studies (both p=0.02) but did not demonstrate a difference in a third study | SOE=Insufficient (No studies)
Calcium Channel Blockers Plus Digoxin vs. Digoxin Alone | SOE=Insufficient (1 study, 52 patients) | SOE=Insufficient (No studies)
Calcium Channel Blockers vs. Digoxin | SOE=High (4 studies, 422 patients) Consistent benefit of verapamil or diltiazem compared with digoxin (p<0.05 across studies) | SOE=Insufficient (No studies)

Abbreviations: KQ=Key Question; SOE=strength of evidence

### KQ 2 Strict Versus Lenient Rate-Control Strategies

Our review identified only one RCT and two observational studies representing secondary analyses of RCTs exploring the comparative safety and effectiveness of strict versus lenient rate-control strategies. Table 24 summarizes the strength of evidence for strict versus lenient rate control and the outcomes of interest. Details about the specific components of these ratings (risk of bias, consistency, directness, and precision) are available in the Results chapter. Across outcomes, data were limited by the number of studies and the imprecision of their findings. We based our findings on the evidence from the one RCT and then evaluated whether the observational studies were consistent or not with these findings. In general, the included studies were consistent in showing no significant difference between strict and lenient rate control with respect to mortality, cardiovascular hospitalizations, heart failure symptoms, quality of life, thromboembolic events, bleeding events, and composite outcomes. However, the RCT differed from the observational studies in showing a statistically significantly lower stroke rate with lenient rate control.

Table 24 Summary of strength of evidence and effect estimate for KQ 2

Outcome | Strength of Evidence and Effect Estimate
All-Cause Mortality | SOE=Insufficient (1 study, 614 patients)
CV Mortality | SOE=Insufficient (2 studies, 828 patients)
CV Hospitalizations | SOE=Insufficient (2 studies, 1,705 patients)
Heart Failure Symptoms | SOE=Insufficient (2 studies, 828 patients)
Quality of Life | SOE=Insufficient (2 studies, 828 patients)
Thromboembolic Events | SOE=Low (2 studies, 828 patients) HR 0.35 (90% CI, 0.13 to 0.92) in RCT favoring lenient control; while also favoring lenient control, the observational study did not demonstrate a statistically significant difference (absolute difference of 1.6; 95% CI -5.3 to 8.6)
Bleeding Events | SOE=Insufficient (2 studies, 828 patients)

Abbreviations: CI=confidence interval; CV=cardiovascular; HR=hazard ratio; KQ=Key Question; RCT=randomized controlled trial; SOE=strength of evidence

### KQ 3 Rate-Control Procedures Versus Drugs or Versus Other Procedures in Patients Failing Initial Pharmacotherapy

Our review identified six RCTs evaluating the comparative effectiveness of a procedural intervention versus a primarily pharmacological intervention for rate control of AF, or comparing two primarily procedural interventions. We also included data from a separately published subgroup analysis of one of the RCTs.

The included studies varied in the types of procedures and pharmacological interventions tested. In line with our a priori definition of rate-control procedures, all studies included at least one treatment arm with radiofrequency ablation of either the AVN or His bundle, most often in conjunction with pacemaker placement. The comparison arms included a pharmacological intervention whose main purpose was to control ventricular heart rate rather than converting the underlying rhythm of AF, based on the description of outcomes; this was combined with a procedure in some studies.

Tables 25 and 26 summarize the strength of evidence for rate-control procedures versus drugs and for one rate-control procedure versus another, respectively. Details about the specific components of these ratings (risk of bias, consistency, directness, and precision) are available in the Results chapter. Across outcomes and comparisons, although the included evidence was from RCTs with an overall low risk of bias and the outcomes were direct, the findings were often imprecise and based on only one or two studies.

Table 25 Summary of strength of evidence and effect estimate for KQ 3—rate-control procedures versus drugs

Outcome | Strength of Evidence and Effect Estimate
Ventricular Rate Control | SOE=Moderate (3 studies, 175 patients) Using different metrics, all 3 studies found that patients in the procedure arm had a significantly lower heart rate at 12 months than those on drugs
All-Cause Mortality | SOE=Low (2 studies, 201 patients) No significant difference
CV Mortality | SOE=Low (1 study, 102 patients) No significant difference
Exercise Capacity | SOE=Low (2 studies, 135 patients) Studies did not show significant differences between procedure and drug arms
Quality of Life | SOE=Insufficient (2 studies,135 patients)

Abbreviations: CV=cardiovascular; KQ=Key Question; SOE=strength of evidence

Table 26 Summary of strength of evidence and effect estimate for KQ 3—one rate-control procedure versus another

Outcome | Strength of Evidence and Effect Estimate
Ventricular Rate Control | SOE=Low (1 study, 40 patients) No difference between those assigned to anterior vs. posterior approach
All-Cause Mortality | SOE=Low (1 study, 184 patients) No significant difference among those in the biventricular pacing group compared with those receiving RV pacing (p=0.16)
Exercise Capacity | SOE=Low (1 study, 184 participants) Improvement in walking distance significantly greater among those in the biventricular pacing group compared with those receiving RV pacing (p=0.04)
Quality of Life | SOE=Insufficient (1 study, 184 participants)

Abbreviations: KQ=Key Question; RV=right ventricular; SOE=strength of evidence

### KQ 4 Antiarrhythmic Drugs and Electrical Cardioversion for Conversion to Sinus Rhythm

Our review identified 42 studies exploring the use of antiarrhythmic drugs and electrical cardioversion for conversion to sinus rhythm. Table 27 summarizes the strength of evidence for the available comparisons and evaluated outcomes. Details about the specific components of these ratings (risk of bias, consistency, directness, and precision) are available in the Results chapter. Across outcomes and comparisons, although the included evidence was from RCTs with an overall low risk of bias and the evidence was based on direct outcomes, some findings were limited in terms of precision and consistency, as well as by the available number of studies.

Table 27 Summary of strength of evidence and effect estimate for KQ 4

Treatment Comparison | Restoration of Sinus Rhythm | Maintenance of Sinus Rhythm | Recurrence of AF
Various Methods for External Electrical Cardioversion (Biphasic vs. Monophasic Waveforms) | SOE=High (4 studies, 411 patients) OR 4.39 (95% CI, 2.84 to 6.78) favoring biphasic waveform | SOE=Insufficient (1 study, 83 patients) | SOE=Low (1 study, 216 patients) No difference
Various Methods for External Electrical Cardioversion (Anterolateral vs. Anteroposterior Cardioversions) | SOE=Low (4 studies, 393 patients) OR 0.87 (95% CI, 0.20 to 3.72) showing potential benefit of anterolateral electrode placement which did not reach statistical significance | SOE=Insufficient (No studies) | SOE=Insufficient (No studies)
Various Methods for External Electrical Cardioversion (Energy Protocols) | SOE=High (3 studies, 432 patients) OR 0.16 (95% CI, 0.05 to 0.53) favoring 360 J vs. 200 J monophasic shock | SOE=Insufficient (No studies) | SOE=Insufficient (No studies)
Drug Enhancement of External Electrical Cardioversion (vs. No Drug Enhancement) | SOE=Moderate (2 studies, 218 patients) No significant benefit for patients given ibutilide or metoprolol pretreatment (p values NR) | SOE=Moderate (2 studies, 195 patients) Significant benefit for patients given verapamil or metoprolol pretreatment (p values of 0.04 and 0.027 in the 2 studies) | SOE=Low (1 study, 88 patients) Significant benefit of verapamil pretreatment (p=0.02)
Drugs for Pharmacological Cardioversion (Amiodarone vs. Sotalol) | SOE=Low (4 studies, 736 patients) OR 1.12 (95% CI, 0.81 to 1.56) demonstrating a potential benefit of amiodarone which did not reach statistical significance | SOE=Insufficient (No studies) | SOE=Insufficient (No studies)
Drugs for Pharmacological Cardioversion (Amiodarone vs. Rate-Control Drugs) | SOE=High (7 studies, 613 patients) OR 2.99 (95% CI, 1.64 to 5.44) demonstrating a significant benefit of amiodarone | SOE=Insufficient (No studies) | SOE=Low (1 study, 152 patients) No difference between amiodarone vs. ibutilide within 24 hours

Abbreviations: AF=atrial fibrillation; CI=confidence interval; J=Joules; KQ=Key Question; NR=not reported; OR=odds ratio; SOE=strength of evidence

### KQ 5 Rhythm-Control Procedures and Drugs for Maintenance of Sinus Rhythm

Our review identified 65 RCTs evaluating procedures for rhythm control and 18 studies evaluating the safety or effectiveness of pharmacological agents with or without external electrical cardioversion for maintaining sinus rhythm in patients with AF.

Tables 28 and 29 summarize the strength of evidence for the evaluated therapies and outcomes. Details about the specific components of these ratings (risk of bias, consistency, directness, and precision) are available in the Results chapter. Across outcomes and comparisons, although the included evidence was from RCTs with an overall low risk of bias and used direct evidence, the findings were often inconsistent or imprecise, limiting our findings.

Table 28 Summary of strength of evidence and effect estimate for KQ 5—procedural rhythm-control therapies

Treatment Comparison | Restoration of Sinus Rhythm | Maintenance of Sinus Rhythm | Recurrence of AF | All-Cause and CV Mortality | CV/AF Hospitalizations | Heart Failure Symptoms/Control of AF Symptoms | Quality of Life | Stroke (and Mixed Embolic Events Including Stroke) | Bleeding Events
Transcatheter PVI vs. AADs | SOE= Insufficient (No studies) | SOE=High (8 studies, 921 patients) OR 6.51 (95% CI, 3.22 to 13.16) favoring transcatheter PVI | SOE= Insufficient (No studies) | All-Cause: SOE= Insufficient (1 study, 69 patients) Cardiac: SOE= Insufficient (No studies) | CV: SOE= Moderate (2 studies, 268 patients) Both studies demonstrated significant increase in CV hospitalizations in the AAD arm vs. PVI AF: SOE= Insufficient (1 study, 67 patients) | SOE= Insufficient (No studies) | SOE= Insufficient (6 studies, 647 patients) | Stroke: SOE= Insufficient (No studies) Mixed: SOE= Low (2 studies, 140 patients) No embolic events in either the PVI or AAD arm | SOE= Insufficient (1 study, 67 patients)
Transcatheter PVI Using Different Types of Ablation Catheters | SOE= Insufficient (No studies) | SOE=Low (3 studies, 264 patients) No difference between different types of ablation catheters | SOE=Low (1 study, 102 patients) No difference between a multipolar circular ablation catheter and a point-by-point PVI with an irrigated tip ablation catheter (p=0.8) | SOE= Insufficient (No studies) | SOE= Insufficient (No studies) | SOE= Insufficient (No studies) | SOE= Insufficient (No studies) | Stroke: SOE= Insufficient (1 study, 82 patients) Mixed: SOE= Insufficient (No studies) | SOE= Insufficient (No studies)
Transcatheter Circumferential PVI vs. Transcatheter Segmental PVI | SOE= Insufficient (1 study, 80 patients) | SOE=Low (5 studies, 500 patients) OR 1.31 (95% CI, 0.59 to 2.93) demonstrating a potential benefit of circumferential PVI which did not reach statistical significance | SOE= Insufficient (No studies) | All-Cause: SOE=Low (1 study, 110 patients) No events in either arm after 48 months Cardiac: SOE= Insufficient (No studies) | SOE= Insufficient (No studies) | SOE= Insufficient (No studies) | SOE= Insufficient (No studies) | SOE= Insufficient (No studies) | SOE= Insufficient (No studies)
Transcatheter PVI With CTI Ablation vs. Transcatheter PVI Without CTI Ablation | SOE= Insufficient (No studies) | SOE= Insufficient (No studies) | SOE= Insufficient (2 studies, 257 patients) | SOE= Insufficient (No studies) | SOE= Insufficient (No studies) | SOE= Insufficient (No studies) | SOE= Insufficient (No studies) | SOE= Insufficient (No studies) | SOE= Insufficient (No studies)
Transcatheter PVI With CFAE Ablation vs. Transcatheter PVI Without CFAE Ablation | SOE=Low (2 studies, 247 patients) 2 studies showing significant benefit of CFAE arm | SOE=Low (9 studies, 817 patients) OR 1.48 (95% CI, 0.74 to 2.98) showing a potential benefit of CFAE which did not reach statistical significance | SOE= Insufficient (No studies) | SOE= Insufficient (No studies) | SOE= Insufficient (No studies) | SOE= Insufficient (No studies) | SOE= Insufficient (1 study, 60 patients) | Stroke: SOE= Low (1 study, 144 patients) No events in any arm after 16 months Mixed: SOE= Insufficient (No studies) | SOE= Insufficient (No studies)
Transcatheter PVI vs. Transcatheter PVI With Additional Ablation Sites Other Than CTI and CFAE and Transcatheter PVI Involving all Four PVs vs. Transcatheter PVI Involving Arrhythmogenic PVs Only | SOE= Insufficient (2 studies, 384 patients) | SOE= Insufficient (15 studies, 1,926 patients) | SOE= Insufficient (6 studies, 572 patients) | All-Cause: SOE= Insufficient (2 studies, 405 patients) Cardiac: SOE= Insufficient (No studies) | SOE= Insufficient (No studies) | SOE= Insufficient (No studies) | SOE=Low (2 studies, 152 patients) No significant difference between arms in 2 studies | Stroke: SOE= Insufficient (2 studies, 361 patients) Mixed: SOE= Insufficient (No studies) | SOE= Insufficient (No studies)
Transcatheter PVI Alone vs. Transcatheter PVI plus Postablation AADs | SOE= Insufficient (No studies) | SOE= Insufficient (No studies) | SOE= Insufficient (2 studies, 217 patients) | SOE= Insufficient (No studies) | CV: SOE= Insufficient (No studies) AF: SOE=Low (1 study, 110 patients) No difference between arms | SOE= Insufficient (No studies) | SOE= Insufficient (No studies) | SOE= Insufficient (No studies) | SOE= Insufficient (No studies)
Surgical Maze vs. Standard of Care (Mitral Valve Surgery) | SOE= Insufficient (No studies) | SOE= Moderate (7 studies, 361 patients) OR 5.80 (95% CI, 1.79 to 18.81) demonstrating large and significant benefit of Maze | SOE= Insufficient (No studies) | All-cause: SOE=Low (6 studies, 384 patients) OR 1.97 (95% CI, 0.81 to 4.80) demonstrating potentially greater mortality with Maze which did not reach statistical significance Cardiac: SOE= Insufficient (No studies) | SOE= Insufficient (No studies) | SOE= Insufficient (1 study, 30 patients) | SOE= Insufficient (No studies) | Stroke: SOE= Insufficient (1 study, 30 patients) Mixed: SOE= Insufficient (1 study, 67 patients) | SOE= Insufficient (1 study, 60 patients)
PVI at the Time of Cardiac Surgery vs. Cardiac Surgery Alone or in Combination with AADs or Catheter Ablation | SOE=High (3 studies, 181 patients) OR 12.30 (95% CI, 1.31 to 115. 29) demonstrating statistically significant benefit of PVI at time of cardiac surgery | SOE=High (8 studies, 532 patients) OR 3.91 (95% CI, 1.54 to 9.91) demonstrating statistically significant benefit of PVI at time of cardiac surgery | SOE= Insufficient (No studies) | All-cause: SOE=Low (2 studies, 88 patients) 2 studies showing no difference between groups Cardiac: SOE= Insufficient (1 study, 97 patients) | SOE= Insufficient (No studies) | SOE= Insufficient (No studies) | SOE= Insufficient (2 studies, 229 patients) | Stroke: SOE=Low (2 studies, 140 patients) 2 studies showing no difference between groups Mixed: SOE= Insufficient (No studies) | SOE= Insufficient (1 study, 43 patients)

Abbreviations: AAD(s)=antiarrhythmic drug(s); AF=atrial fibrillation; CFAE=complex fractionated atrial electrogram; CI=confidence interval; CTI=cavotricuspid isthmus; CV=cardiovascular; KQ=Key Question; NA=not applicable; OR=odds ratio; PV(s)=pulmonary vein(s); PVI=pulmonary vein isolation; SOE=strength of evidence

Table 29 Summary of strength of evidence and effect estimates for KQ 5—pharmacological rhythm-control therapies

Treatment Comparison | Restoration of Sinus Rhythm | Maintenance of Sinus Rhythm | Recurrence of AF | All-Cause and CV Mortality | AF and CV Hospitalizations | Heart Failure Symptoms/Control of AF Symptoms | Quality of Life | Stroke (and Mixed Embolic Events Including Stroke) | Bleeding Events
Pharmacological Therapy in Which Electrical Cardioversion is a Key Component of the Treatment | SOE= Insufficient (No studies) | SOE= Insufficient (1 study, 168 patients) | SOE= Insufficient (4 studies, 414 patients) | All-cause: SOE= Insufficient (1 study, 168 patients) Cardiac: SOE= Insufficient (No studies) | SOE= Insufficient (No studies) | SOE= Insufficient (No studies) | SOE= Insufficient (1 study, 144 patients) | Stroke: SOE= Insufficient (1 study, 168 patients) Mixed: SOE= Insufficient (No studies) | SOE= Insufficient (No studies)
Comparison of Pharmacological Agents | SOE= Insufficient (No studies) | SOE=Low (9 studies, 2,095 patients) Amiodarone appears better than sotalol, but no different from propafenone | SOE=Low (10 studies, 3,223 patients) Amiodarone appears better than dronedarone or sotalol, but no different from propafenone | All-Cause: SOE= Insufficient (5 studies, 2,076 patients) Cardiac: SOE= Low (4 studies, 1,664 patients) No difference between study arms in arrhythmic deaths | CV: SOE= Insufficient (No studies) AF: SOE=Low (1 study, 403 patients) Rate and mean length of stay of AF hospitalization were lower with amiodarone than with sotalol or propafenone | Heart Failure: SOE= Insufficient (No studies) AF Symptoms: SOE=Low (1 study, 403 patients) No difference between amiodarone versus sotalol or propafenone | SOE=Low (2 studies, 1,068 patients) No significant difference in either study | Stroke: SOE= Insufficient (2 studies, 1,068 patients) Mixed: SOE= Insufficient (No studies) | SOE= Insufficient (No studies)

Abbreviations: AF=atrial fibrillation; CV=cardiovascular; KQ=Key Question; SOE=strength of evidence

### KQ 6 Rate- Versus Rhythm-Control Therapies

A total of 14 RCTs were included in our analysis, 12 that explored a rhythm-control strategy using pharmacological therapy versus a rate-control strategy, and 2 that compared a rhythm-control strategy with PVI versus a rate-control strategy that involved AVN ablation and implantation of a pacemaker in one case and rate-controlling medications in the other.

Table 30 summarizes the strength of evidence for the rate- and rhythm-control therapies and evaluated outcomes. Details about the specific components of these ratings (risk of bias, consistency, directness, and precision) are available in the Results chapter.

Table 30 Summary of strength of evidence and effect estimate for KQ 6—rate- versus rhythm-control strategies

Outcome | Strength of Evidence and Effect Estimate
Maintenance of Sinus Rhythm | [underlined: Using AADs for Rhythm Control:] SOE=High (7 studies, 1,473 patients) OR 0.18 (95% CI, 0.11 to 0.28) favoring rhythm-control strategies [underlined: Using PVI for Rhythm Control:] SOE=Low (2 studies, 122 patients) Significantly better in rhythm-control strategies (OR not reported)
Ventricular Rate Control | [underlined: Using AADs for Rhythm Control:] SOE=Low (2 studies, 727 patients) Significantly better in rhythm-control strategies
All-Cause Mortality | [underlined: Using AADs for Rhythm Control:] SOE=Moderate (8 studies, 6,372 patients) OR 1.34 (95% CI, 0.89 to 2.02) demonstrating a potential benefit of a rhythm-control strategy which did not reach statistical significance. Since 6 of the 8 studies had ORs that crossed 1 (including 95% of the patients), and given significant heterogeneity, we assessed these studies as demonstrating no difference between rate- and rhythm-control strategies.
CV Mortality | [underlined: Using AADs for Rhythm Control:] SOE=Moderate (5 studies, 2,405 patients) OR 0.96 (95% CI, 0.77 to 1.20) demonstrating no difference between rate- and rhythm-control strategies
Myocardial Infarction | [underlined: Using AADs for Rhythm Control:] SOE=Low (2 studies, 246 patients) Both studies showed no significant difference between rate- and rhythm-control strategies
CV Hospitalizations | [underlined: Using AADs for Rhythm Control:] SOE=High (3 studies, 439 patients) OR 0.25 (95% CI, 0.14 to 0.43) favoring rate-control strategies
Heart Failure Symptoms | [underlined: Using AADs for Rhythm Control:] SOE=Low (4 studies, 1,700 patients) OR 0.78 (95% CI, 0.42 to 1.44) showing a potential benefit of rhythm control which did not reach statistical significance
Quality of Life | [underlined: Using AADs for Rhythm Control:] SOE=Insufficient (9 studies, 5,806 patients) [underlined: Using PVI for Rhythm Control:] SOE=Insufficient (2 studies, 122 patients)
Stroke | [underlined: Using AADs for Rhythm Control:] SOE=Moderate (8 studies, 6,424 patients) OR 0.99 (95% CI, 0.76 to 1.30) demonstrating no difference between rate- and rhythm-control strategies
Mixed Embolic Events Including Stroke | [underlined: Using AADs for Rhythm Control:] SOE=Low (3 studies, 866 patients) OR 1.24 (95% CI, 0.37 to 4.09) demonstrating a potential benefit of rhythm-control strategies which did not reach statistical significance
Bleeding Events | [underlined: Using AADs for Rhythm Control:] SOE=Moderate (5 studies, 5,072 patients) OR 1.10 (95% CI, 0.87 to 1.38) demonstrating no difference between rate- and rhythm-control strategies

Abbreviations: AADs=antiarrhythmic drugs; CI=confidence interval; CV=cardiovascular; KQ=Key Question; OR=odds ratio; PVI=pulmonary vein isolation; SOE=strength of evidence

## Findings in Relationship to What Is Already Known

In general, there are two broad strategies for AF management—a rate-control strategy and a rhythm-control strategy. While some have argued that being in sinus rhythm is superior to being in AF, restoration and maintenance of sinus rhythm are not always easy, and the required therapies may pose harms, thus raising the fundamental question of whether a strategy focused only on controlling the ventricular rate as opposed to being focused on restoring and maintaining sinus rhythm may be safer and more effective. To further complicate treatment decisions, there are many pharmacological and nonpharmacological methods for controlling ventricular rate and for restoring and maintaining sinus rhythm; therefore, a complete understanding of the comparative safety and effectiveness of treatments within each strategy is needed for optimal treatment.

Because our review was restricted to evidence published in 2000 or later, it is important to summarize what was known based on the evidence prior to 2000 to allow our findings to be viewed in context. As summarized in the 2001 AHRQ report on the Management of New Onset Atrial Fibrillation,25-27 several medications were found to be efficacious in conversion of AF and subsequent maintenance of sinus rhythm. Unfortunately, as described below, these findings were largely based on comparisons with placebo or control therapy rather than with other active agents, and therefore the scope of this previous review is not directly applicable to that of this current comparative effectiveness review. Specifically, flecainide (OR 24.7; 95% CI, 9.0 to 68) and ibutilide/dofetilide (OR 29.1; 95% CI, 9.8 to 86) demonstrated the strongest evidence of successful conversion when compared with control. Strong evidence of efficacy with a fairly large treatment effect size also existed for propafenone (OR 4.6; 95% CI, 2.6 to 8.2). Quinidine had moderate evidence of efficacy and a modest treatment effect size compared with control treatment (OR 2.9; 95% CI, 1.2 to 7.0). Disopyramide (OR 7.0; 95% CI, 0.3 to 152) and amiodarone (OR 5.7; 95% CI, 1.0 to 33.4) had suggestive evidence of efficacy, while sotalol (OR 0.4; 95% CI 0.0 to 3.0) had suggestive evidence of negative efficacy for conversion. For maintenance of sinus rhythm, strong evidence of efficacy when compared with control treatment existed for quinidine (OR 4.1; 95% CI, 2.5 to 6.7), disopyramide (OR 3.4; 95% CI, 1.6 to 7.1), flecainide (OR 3.1; 95% CI, 1.5 to 6.2), propafenone (OR 3.7; 95% CI, 2.4 to 5.7), and sotalol (OR 7.1; 95% CI, 3.8 to 13.4). For rate control, the design and outcome measures of included trials were too disparate for meta-analysis. In general, however, the evidence suggested that calcium channel blockers and some beta blockers were effective for controlling heart rate during exercise. Although the evidence for several individual therapies compared with control or placebo was strong, the lack of evidence supporting the comparative effectiveness of these therapies highlights the need for the current report.

In the United States, the 2006 Guidelines for the Management of Patients with Atrial Fibrillation—prepared jointly by the American College of Cardiology (ACC), the American Heart Association (AHA), and the European Society of Cardiology (ESC)14 —along with a focused update in 2011 by the ACC, AHA, and Heart Rhythm Society,16 now serves as the primary resource for synthesized evidence and treatment recommendations. Published randomized controlled trials (RCTs), prior meta-analyses, and the above-mentioned Guidelines indicated that there did not appear to be a significant difference in outcomes of a rate- versus rhythm-control strategy; however, the results were driven primarily by one study (the Atrial Fibrillation Follow-Up Investigation of Rhythm Management [AFFIRM] trial.155 Unlike AFFIRM and prior meta-analyses, in the current systematic review we included more patients and gathered data on multiple outcome measures from all studies comparing a rate-control strategy with a pharmacological rhythm-control strategy and also looked for studies using nonpharmacological rate- and rhythm-control treatments. We found no statistically significant difference in all-cause mortality or cardiovascular mortality between a rate-control strategy and a rhythm-control strategy using antiarrhythmic drugs, which is consistent with prior reviews. Our review extends beyond the findings of prior reviews, as it shows no significant difference in stroke or bleeding events between the strategies and shows a potential benefit of rhythm control for reduction in heart failure symptoms which, however, did not reach statistical significance. Our review confirms the findings of AFFIRM regarding all these outcomes. Confirming the findings related to heart failure symptoms and bleeding events is of particular interest due to the relatively small number of these events in AFFIRM. As expected, the rhythm-control strategy was associated with better maintenance of sinus rhythm than the rate-control strategy.

Our review also looked specifically at comparisons of pharmacological and nonpharmacological rate-control therapies, including comparisons of lenient versus strict rate control. We found that digoxin was generally less effective than other rate-control therapies, which was consistent with prior evidence and guidelines. Also consistent with prior knowledge was the lack of definitive evidence for better rate control with beta blockers as compared with verapamil or diltiazem, and a general lack of information on comparative safety of the agents overall and within specific patient subgroups. Our review highlights the lack of data on the superiority of one beta blocker over another, which we hope will challenge current assumptions regarding the superiority of one beta-blocker over another and highlight the need for well-designed RCTs addressing this issue. Amiodarone has previously been considered an alternative to other rate-control drugs when those other drugs fail. In this review, amiodarone appeared comparable to diltiazem and better than digoxin for rate control, but due to the small number of patients and relative lack of comparable safety data, these results do not substantially modify prior clinical assumptions. Sotalol was also evaluated as a rate-control treatment, but due to a small number of studies and lack of comparable safety data, the results are inconclusive. Nonpharmacological therapies for rate control were compared with pharmacological therapy in only five RCTs, and none of these evaluated final clinical outcomes such as mortality. Differences in methods for assessing outcomes such as quality of life made comparisons across studies challenging. Patients receiving nonpharmacological rate-control therapies generally had lower heart rates, but as stated above, other important outcomes were not well addressed or comparable. This vast lack of data on final outcomes underscores the importance of doing well-designed studies evaluating these outcomes in patients receiving rate-controlling medications versus those receiving rate-controlling procedures. This lack of data should be highlighted in counseling patients about the alternative therapies available to control their heart rate.

Although we found limited data on the question of use of a lenient rate control versus strict rate control, by emphasizing the limitations in the available data and the paucity of data on lenient versus strict rate control, our findings highlight the need for more research in this area. In addition to one RCT (Rate Control Efficacy in Permanent Atrial Fibrillation-II [RACE-II] trial17), two observational studies that were secondary analyses of RCTs were included to address this question.152,153 Consistent with the results of the single RCT, no differences in all-cause mortality, cardiovascular mortality, heart failure symptoms, cardiovascular hospitalizations, quality of life, or control of AF symptoms were found between lenient versus strict rate control.

With regard to rhythm-control therapies, external electrical cardioversion is known to be more effective than antiarrhythmic drugs in acute conversion of AF to sinus rhythm and thus not addressed in our review. We focused instead on the comparative safety and effectiveness of drugs and procedures for the acute restoration of sinus rhythm and for longer term maintenance of sinus rhythm. By showing that biphasic cardioversion is superior to monophasic cardioversion we confirmed the findings of prior reviews. Despite strongly held beliefs about the superiority of one positioning of cardioversion electrodes over another, we found no significant difference in restoration of sinus rhythm with use of an anterolateral versus anteroposterior positioning of cardioversion electrodes, although with a low strength of evidence for this finding. While data suggest that drug pretreatment enhances electrical cardioversion in terms of restoration and maintenance of sinus rhythm, our review does not support the current assumption that one antiarrhythmic medication is clearly superior to others in such pretreatment. Given the widespread use of these drugs, more studies are needed comparing the effectiveness and safety of different antiarrhythmic medications in enhancing restoration of sinus rhythm.

PVI is currently recommended as a second- or third-line therapy for patients with AF and is used only after antiarrhythmic drug therapy has failed. Although data continue to be needed on final clinical outcomes such as all-cause mortality, stroke, and heart failure, there was substantial evidence supporting the use of PVI versus antiarrhythmic drugs for reducing recurrences of AF in patients with paroxysmal AF who were younger, and who had only mild structural heart disease and mild left atrium enlargement. These studies mostly examined PVI as second-line therapy. One recent study compared PVI with antiarrhythmic medications as first-line therapy in patients with paroxysmal AF. It found no significant difference in the burden of AF over a period of 2 years.306 More studies are needed on PVI as first-line therapy. The effect of PVI on final outcomes including mortality is being assessed by the ongoing NHLBI-funded Catheter Ablation versus Antiarrhythmic Drug Therapy for AF (CABANA) trial. There was less evidence supporting use of PVI versus antiarrhythmic drugs in similar types of patients with persistent AF. By combining data from nine RCTs, our review is the largest to date to address the clinical question of whether CFAE ablation in addition to PVI is better than PVI only at maintaining sinus rhythm. Unlike prior studies, our review showed that CFAE ablation in addition to PVI did not significantly increase maintenance of sinus rhythm compared with PVI alone.88,97 This difference is largely driven by the inclusion of two recent studies216,223 not included in prior reviews which did not demonstrate a benefit of CFAE. One of these studies was limited to patients with persistent AF, which raises questions about the influence of type and duration of AF on the outcomes of CFAE ablation. This underscores the importance of conducting well-powered and well-designed RCTs to address this issue definitively, especially as it relates to appropriate patient selection for CFAE ablation.

In addition, a surgical Maze procedure at time of other cardiac surgery (specifically mitral valve surgery) was superior to mitral valve surgery alone in reducing AF recurrences in patients with persistent AF. Data on final clinical outcomes such as all-cause mortality associated with surgical Maze were largely absent. Likewise, rhythm control using PVI at the time of cardiac surgery is superior to cardiac surgery alone or in combination with AAD or with catheter ablation in reducing AF recurrence over 12 months of followup in patients with persistent AF. This supports exploring these interventions further with regard to their effect on final outcomes and in different patient populations.

In examining the comparative effectiveness of different antiarrhythmic medications for reducing mortality, we found only one study, a substudy of the AFFIRM study, that systematically assessed differences in mortality between antiarrhythmic drugs and found no statistically significant difference between amiodarone and sotalol. We found no data on the comparative effectiveness of different antiarrhythmic medications in relation to other final outcomes. Most studies examined the effect of different antiarrhythmic medications on the maintenance of sinus rhythm; amiodarone, sotalol, and propafenone were the most frequently studied antiarrhythmic drugs in RCTs. With regard to maintaining sinus rhythm or decreasing recurrences of AF, amiodarone did not appear to be different from propafenone in the two studies of fair quality that reported results on this comparison. Comparisons of other antiarrhythmic drugs were infrequent and often led to conflicting results. Indeed, the superiority of one antiarrhythmic medication over another has been debated for years, and there has been a long-standing need to better understand the comparative effectiveness of different antiarrhythmic medications at maintaining sinus rhythm. Our findings further highlight the importance of future research to compare different antiarrhythmic medications.

## Applicability

Table 31 illustrates the specific issues with the applicability of our included evidence base by KQ. Although the included studies were conducted in a broad range of geographic locations, we note that the 2006 AF guidelines that have guided our management of AF for the past 6 years was put together by ACC, AHA and the ESC. We believe that clinical practices across the geographic locations are more similar than different and not a major detriment to the evidence base applicability. One question is why more studies are conducted outside of the United States. Although the reason for this is unknown, it is most likely partially driven both by fewer regulations and greater ease of patient enrollment.

Table 31 Potential issues with applicability of included studies

Issues | Key Question
Issues | KQ 1 N=14 | KQ 2 N=3 | KQ 3 N=6 | KQ 4 N=42 | KQ 5 N=83 | KQ 6 N=14 | Total N=148
Population (P)
Narrow eligibility criteria and exclusion of those with comorbidities | 2 | 0 | 1 | 1 | 6 | 3 | 12
Large differences between demographics of study population and community patients | 1 | 0 | 0 | 6 | 16 | 2 | 22
Narrow or unrepresentative severity, stage of illness, or comorbidities | 0 | 1 | 0 | 2 | 2 | 1 | 5
Run-in period with high exclusion rate for nonadherence or side effects | 0 | 0 | 0 | 2 | 0 | 0 | 2
Event rates much higher or lower than observed in population-based studies | 0 | 0 | 0 | 1 | 0 | 0 | 1
Intervention (I)
Doses or schedules not reflected in current practice | 1 | 0 | 0 | 2 | 2 | 0 | 5
Monitoring practices or visit frequency not used in typical practice | 0 | 0 | 0 | 0 | 0 | 0 | 0
Older versions of an intervention no longer in common use | 0 | 0 | 0 | 7 | 3 | 0 | 10
Cointerventions that are likely to modify effectiveness of therapy | 2 | 0 | 0 | 4 | 7 | 0 | 9
Highly selected intervention team or level of training/proficiency not widely available | 0 | 0 | 4 | 0 | 40 | 2 | 45
Comparator (C)
Inadequate comparison therapy | 0 | 0 | 0 | 5 | 2 | 1 | 7
Use of substandard alternative therapy | 0 | 0 | 0 | 4 | 3 | 1 | 8
Outcomes (O)
Composite outcomes that mix outcomes of different significance | 0 | 1 | 1 | 0 | 4 | 2 | 8
Short-term or surrogate outcomes | 13 | 0 | 2 | 31 | 12 | 4 | 55
Setting (S)
Standards of care differ markedly from setting of interest | 0 | 0 | 0 | 0 | 1 | 0 | 1
Specialty population or level of care differs from that seen in community | 0 | 0 | 0 | 0 | 0 | 0 | 0

Abbreviation: KQ=Key Question

As demonstrated in Table 31, the main issues related to applicability of the evidence base included concerns about short-term or surrogate outcomes (37% of studies), whether the intervention team or level of training represented in the study would be widely available (30% of studies), and large potential differences between the study population and community patients (15% of studies).

## Implications for Clinical and Policy Decisionmaking

Management of AF in contemporary clinical practice is complex and challenging. Being in sinus rhythm as compared with AF may benefit patients; however, benefits associated with being in sinus rhythm may not always outweigh the risks associated with available methods to restore sinus rhythm. Therefore, clinicians and patients are faced with difficult decisions not only in determining an appropriate general strategy (rate or rhythm control) but also in determining the optimal treatment within the selected strategy. At the time the current U.S. guidelines for management of AF were developed (developed in 2006 and then the topic of a focused update in 2011) there were few direct comparisons between specific drugs/procedures or even between the general rate- versus rhythm-control strategies. Since that time, relatively few comparative studies have been conducted, and those that have been done have been primarily focused on intermediary outcomes rather than final outcome measures such as mortality. Given the risks associated with AF, the growing number of patients with AF, and the costs and risks associated with treatments for AF, a better understanding of comparative safety and effectiveness of therapies is of paramount importance.

As new drugs and new procedures are introduced, determining their relative risks and benefits in the overall AF management scheme minimizes the use of potentially less effective, more costly, and less safe therapies. Although the current CER is consistent with existing guidelines, it strengthens the findings in these guidelines and helps to identify gaps in the evidence base and areas of needed future research.

## Limitations of the Evidence Base and the Comparative Effectiveness Review Process

Our findings have limitations related to the literature and our approach. Important limitations of the literature across the KQs include: (1) few studies in specific patient subgroups of interest; (2) few studies that assess long term clinical outcomes, including mortality, cardiac events, and stroke, as well as adverse effects; (3) few studies that compare specific rate- or rhythm-control strategies across similar outcomes allowing quantitative synthesis; (4) narrow eligibility criteria of included studies and exclusion of those with comorbidities; (5) trials of procedures which use highly selected intervention teams; and (6) inadequate comparison therapies in terms of representing either standard of care of novel alternative therapy. Specific to the clinical outcomes evaluated in this literature, one of the main outcomes assessed is AF recurrence. We note, however, that there are several limitations to this outcome; findings should therefore be viewed with caution. Specifically, recurrences of AF may be asymptomatic in many patients, and in the absence of continual ECG monitoring these episodes could be missed. Continual ECG monitoring is not routinely done due to the cumbersomeness of the monitoring devices and the long period of time that these devices would need to be worn. In addition, symptoms alone have recently been shown to underestimate postablation AF burden.307 Furthermore, recurrent episodes of AF may be of varying lengths of time from seconds to months. This wide variation in duration may have very different effects on the development of other clinically important outcomes such as exacerbation of heart failure or development of stroke.

Our review methods also had limitations. Our study was limited to English-language publications. It was the opinion of the investigators and the Technical Expert Panel (TEP) that the resources required to translate non-English articles would not be justified by the low potential likelihood of identifying relevant data unavailable from English-language sources. We do note, however, that many of our included studies were conducted in Europe and there is the possibility that negative studies from such geographic locations might not have been translated into English, resulting in publication bias. Our review of ClinicalTrials.gov did not, however, provide evidence of this concern. We also limited our analysis to RCTs except for specific key questions (KQ 2 and KQ 5, focusing on cardiac resynchronization therapy). Although the inclusion of observational studies would have expanded the evidence base for our review, it was the opinion of the investigators and the TEP that the resources needed to include the potential observational studies would not be justified given the number of RCTs available and the potential risk for bias intrinsic in the observational evidence. These studies, however, may have provided additional useful information on safety and effectiveness data in patients with comorbidities and adverse events. Our review is also limited in that the evidence included in our synthesis is based on the published literature rather than through direct access to the included studies' datasets or collaboration with the primary authors. This restriction means that the methods described within an included article for a specific study, or the description of a particular outcome of interest, may not be sufficiently detailed for us to determine the relevance of a study's population, interventions, or outcomes for our review. Finally, as a comparative effectiveness study, we restricted our analysis to studies that compared two active therapies for AF and did not include placebo-controlled trials. Inclusion of such placebo-controlled trials may have allowed additional quantitative analyses to be performed used mixed treatment meta-analyses.

## Research Gaps

AF is one of the most common arrhythmias and is associated with increased morbidity, increased mortality, and high health-related costs. There are several established treatments for both rate control and rhythm control, as well as newer pharmacological and procedural treatments for both. In our analyses, we found research gaps related to patient-centered outcomes for both established as well as newer therapies. We used the framework recommended by Robinson et al. to identify gaps in evidence and describe why these gaps exist.308 This approach considers PICOTS (Populations, Interventions, Comparators, Outcomes, Timings, and Settings of interest) to identify gaps and classifies gaps as due to (a) insufficient or imprecise information; (b) biased information; (c) inconsistency or unknown consistency; and (d) not the right information. Results are as follows:

### KQ 1 Research Gaps: Rate-Control Drugs

Evidence gaps in the comparative effectiveness of rate-control drugs specifically included:

- What are the comparative safety and effectiveness of pharmacological agents used for ventricular rate control in patients with AF in terms of their impact on long-term outcomes of all-cause mortality, cardiovascular mortality, or other cardiovascular-related outcomes?
- Do the comparative safety and effectiveness of these therapies differ among specific patient subgroups of interest including patients stratified by age, with different types of AF, for whom a prior rate- or rhythm-control strategy was ineffective, with specific comorbidities, by sex, with an enlarged left atrium, or those at high risk for stroke and bleeding events?
- What are the comparative safety and effectiveness of specific beta-blockers used for ventricular rate control in patients with AF?

Fourteen RCTs compared the different pharmacological agents and their impact on outcomes of interest. No comparator studies included evaluated long-term outcomes of all-cause mortality, cardiovascular mortality, or other cardiovascular-related outcomes. Based on our analyses, more RCTs are needed comparing different rate-control agents among general patients with AF, as well as in patients with AF and heart failure. We identified only one study comparing the effectiveness of different beta blockers. Given that beta blockers are some of the most commonly used drugs for rate control, additional comparative studies are needed. Of particular interest would likely be the comparison between the beta blockers metoprolol and carvedilol, both of which are commonly used but which have different properties that could make them more suitable for certain subgroups of patients (e.g., patients with heart failure). An additional area of future research would be the exploration of beta blockers and calcium channel blockers used together. Patients in these studies should be followed long term to determine long-term outcomes.

### KQ 2 Research Gaps: Strict Versus Lenient Rate-Control Strategies

Evidence gaps in the comparative effectiveness of strict versus lenient rate-control strategies include:

- What are the comparative safety and effectiveness of a strict rate-control strategy versus a more lenient rate-control strategy in patients with AF?
- Do the comparative safety and effectiveness of these therapies differ among specific patient subgroups of interest including patients stratified by age, with different types of AF, for whom a prior rate- or rhythm-control strategy was ineffective, with specific comorbidities, by sex, with an enlarged left atrium, or those at high risk for stroke and bleeding events?

Unfortunately very few studies, and only one RCT, examined the comparative effectiveness of a strict rate-control strategy versus a more lenient rate-control strategy in patients with AF. In addition, no clear subgroups of interest were examined in the single RCT included in this analysis. This RCT was, however, of good quality and found no significant difference in outcomes among patients treated with strict or lenient rate control except for stroke risk, which favored lenient rate control. However, further studies are needed that are adequately powered to evaluate clinically meaningful outcomes, including stroke risk, and these studies should also be carried out among general patients with AF but also among subgroups of patients, such as those with heart failure. In order to better compare future studies, achieving consensus on standardized definitions of strict and lenient rate control is needed. There also remains a need to define how best to assess the adequacy of rate control. Some investigators have relied on periodic Holter monitoring, but it remains unclear whether this is the best way to assess this important outcome.

### KQ 3 Research Gaps: Rate-Control Procedures Versus Drugs in Patients for Whom Initial Pharmacotherapy Was Ineffective

Evidence gaps in the comparative effectiveness of rate-control procedures versus drugs in patients for whom initial pharmacotherapy was ineffective include:

- What are the comparative safety and effectiveness of newer procedural and other nonpharmacological rate-control therapies compared with pharmacological agents in patients with AF for whom initial pharmacotherapy was ineffective?
- Do the comparative safety and effectiveness of these therapies differ among specific patient subgroups of interest including patients stratified by age, with different types of AF, for whom a prior rate- or rhythm-control strategy was ineffective, with specific comorbidities, by sex, with an enlarged left atrium, or those at high risk for stroke and bleeding events?

Six RCTs examined this question but compared fairly different treatments for rate control, thus limiting our ability to combine studies to strengthen the power of these results. In terms of assessing subgroups of interest, only one study compared the comparative effectiveness of treatments among patients with a left ventricular ejection fraction (LVEF) ≤45 percent.

Given the renewed interest in treatment of AF with rate-control therapies, it is somewhat surprising how few studies compared the effectiveness of different rate-control strategies. Further study is needed to evaluate AVN (or His bundle) ablation with pacemaker as well as specific rate-control agents for rate control and symptom management for patients who cannot tolerate pharmacological therapies. AVN ablation with pacemaker placement needs to be studied further regarding its effects on patients with different AF duration, type of AF, or underlying conditions such as heart failure. Further study is also needed to evaluate additional pacing strategies and the use of concomitant biventricular pacing. The timing of AVN ablation and pacemaker implantation needs to be better defined given that this procedure is one of last resort in patients with AF. All of the above treatment strategies should be evaluated in subgroups of interest such as sex, age, left ventricular function, and other comorbidities. In addition, further studies are needed to determine if treatment outcomes vary in patients with different types of AF.

### KQ 4 Research Gaps: Antiarrhythmic Drugs and Electrical Cardioversion for Conversion to Sinus Rhythm

Evidence gaps in the comparative effectiveness of antiarrhythmic drugs and electrical cardioversion for conversion to sinus rhythm include:

- What are the comparative safety and effectiveness of available antiarrhythmic agents and electrical cardioversion procedures for conversion of AF to sinus rhythm?
- Do the comparative safety and effectiveness of these therapies differ among specific patient subgroups of interest including patients stratified by age, with different types of AF, for whom a prior rate- or rhythm-control strategy was ineffective, with specific comorbidities, by sex, with an enlarged left atrium, or those at high risk for stroke and bleeding events?

Although 42 studies evaluated different approaches to cardioversion, the treatment arms were highly divergent and outcomes of interest were not reported for specific subgroups. Therefore, future research in this area needs to focus on subgroups of interest, in particular patients with underlying heart disease or heart failure. Differences in the comparative effectiveness of such treatments may also exist by sex, race, or age of patients. In addition, further research is needed to determine the most appropriate subsequent treatment step following a failed electrical cardioversion. A specific area for future research would be to explore the risk for proarrhythmias especially in women (and particularly with certain medications like dofetilide).

### KQ 5 Research Gaps: Rhythm-Control Procedures and Drugs for Maintenance of Sinus Rhythm

Evidence gaps in the comparative effectiveness of rhythm-control drugs and procedures for the maintenance of sinus rhythm include:

- What are the comparative safety and effectiveness of newer procedural rhythm-control therapies, other nonpharmacological rhythm-control therapies, and pharmacological agents (either separately or in combination with each other) for maintenance of sinus rhythm in patients with AF?
- Do the comparative safety and effectiveness of these therapies differ among specific patient subgroups of interest including patients stratified by age, with different types of AF, for whom a prior rate- or rhythm-control strategy was ineffective, with specific comorbidities, by sex, with an enlarged left atrium, or those at high risk for stroke and bleeding events?

Sixty-two studies evaluated the comparative effectiveness of the relatively newer procedural rhythm-control therapies. However, these studies were not conducted in subgroups of interest and in general did not evaluate longer term outcomes. Despite the large number of trials, there is a need for further study to determine the comparative effectiveness of these procedures on longer term outcomes, including mortality, the occurrence of stroke, and heart failure. It is not clear if certain procedures achieve better outcomes in subgroups of patients, based either on underlying cardiac characteristics or duration or type of AF. It is also not clear if anticoagulation can be stopped safely after rhythm control has been achieved or the timing of this. Further study is needed on issues related to quality of life and cost.

Although there are numerous drug therapies available for rhythm control of AF, the included RCTs all compare different combinations of drugs, limiting our ability to synthesize these results to increase their power. In addition, most studies of drug therapies reported outcomes related to rhythm control, while fewer reported long-term outcomes or complications related to therapy. Six studies did evaluate outcomes by subgroups of interest; however, these studies generally evaluated outcomes of rhythm control. Five studies reported longer-term outcomes, but these outcomes were not reported for subgroups of interest. Only one study evaluated quality of life, and the agents compared—digoxin and verapamil—are generally not used for rhythm control. Future studies are needed to compare the effectiveness of the most commonly used agents for rhythm control, and future studies are needed to evaluate longer-term outcomes, including mortality and cardiac outcomes such as heart failure, as well as outcomes related to adverse effects and quality of life, particularly for agents such as amiodarone which are known to have the potential for significant adverse effects. Unfortunately, long-term studies involving procedures are often difficult to design and execute. In addition to the need for significant resources, there are issues of cross over between arms, lack of compliance with the therapy, and loss of patients back to their referring physician making long-term followup difficult.

### KQ 6 Research Gaps: Rate- Versus Rhythm-Control Therapies

Evidence gaps in the comparative effectiveness of rate- and rhythm-control strategies include:

- What are the comparative safety and effectiveness of rate-control therapies versus rhythm-control therapies in patients with AF?
- Does the comparative safety and effectiveness of these therapies differ among specific patient subgroups of interest including patients stratified by age, with different types of AF, for whom a prior rate- or rhythm-control strategy was ineffective, with specific comorbidities, by sex, with an enlarged left atrium, or those at high risk for stroke and bleeding events?

Fourteen RCTs evaluated the comparative effectiveness of rate-control therapies versus rhythm-control therapies in patients with AF; however, few of these studies examined this issue in subgroups of interest. While studies have shown that a rate-control strategy is at least as good as a rhythm-control strategy, this may be only true in patients similar to the patients enrolled in the clinical trials; i.e., older patients with no debilitating symptoms due to AF. Studies that focus on younger patients or patients with more symptomatic AF would be of interest to the clinical and policymaking community. Also, trials evaluating longer term outcomes tended to be trials that included pharmacological agents, particularly for rhythm control. Few studies compared rate-control therapies to procedural-based rhythm-control therapies, which could be associated with fewer adverse effects than antiarrhythmic drug therapy. These newer procedural-based rhythm-control therapies should be compared with rate-control therapies for longer term outcomes including mortality, cardiac events, and stroke, as well as for adverse effects.

## Conclusions

In assessing clinical outcomes associated with rate- versus rhythm-control strategies, our review of recent evidence agrees with prior reviews demonstrating little overall difference in outcomes between these two strategic approaches. However, it is important to acknowledge that these studies have focused primarily on a subset of patients with AF (typically older patients with fewer symptoms), and differences between the strategic approaches in other patients are largely unknown. In addition, there is a wide range of options within each strategic approach. Very few studies evaluated the comparative safety and effectiveness of specific rate-control drugs or procedures especially within specific subgroups of patients who are likely to be encountered in clinical practice (such as those with heart failure). In addition, very few studies were done to assess outcomes associated with strict versus more lenient rate-control targets. The wide variety of rhythm-control drugs and procedures also posed a challenge to quantitative assessments of the comparative safety and effectiveness of these different drugs and procedures. Importantly, the review highlights the need for more data on the effect of these procedures on final outcomes such as mortality, stroke, and cardiovascular hospitalizations.