# Study Characteristics Tables

The tables in this appendix summarize basic study characteristics for each Key Question (KQ). A comprehensive list of references is provided at the end of the appendix.

Appendix Table F-1 Study characteristics—KQ 1

Appendix Table F-2 Study characteristics—KQ 2

Appendix Table F-3 Study characteristics—KQ 3

Appendix Table F-4 Study characteristics—KQ 4

Appendix Table F-5 Study characteristics—KQ 5

Appendix Table F-6 Study characteristics—KQ 6

## References to Appendix F

1 Capucci A, Villani GQ, Aschieri D, et al. Oral amiodarone increases the efficacy of direct-current cardioversion in restoration of sinus rhythm in patients with chronic atrial fibrillation. Eur Heart J. 2000;21(1):66-73. [pmid: 10610746].
2 Holming K. The effect of digitalis or a beta-blocker, alone or in combination, on atrial fibrillation at rest and during exercise. Ups J Med Sci. 2001;106(1):77-8. [pmid: 11817566].
3 Delle Karth G, Geppert A, Neunteufl T, et al. Amiodarone versus diltiazem for rate control in critically ill patients with atrial tachyarrhythmias. Crit Care Med. 2001;29(6):1149-53. [pmid: 11395591].
4 Kochiadakis GE, Kanoupakis EM, Kalebubas MD, et al. Sotalol vs metoprolol for ventricular rate control in patients with chronic atrial fibrillation who have undergone digitalization: a single-blinded crossover study. Europace. 2001;3(1):73-9. [pmid: 11271956].
5 Simpson CS, Ghali WA, Sanfilippo AJ, et al. Clinical assessment of clonidine in the treatment of new-onset rapid atrial fibrillation: a prospective, randomized clinical trial. Am Heart J. 2001;142(2):E3. [pmid: 11479482].
6 Wattanasuwan N, Khan IA, Mehta NJ, et al. Acute ventricular rate control in atrial fibrillation: IV combination of diltiazem and digoxin vs. IV diltiazem alone. Chest. 2001;119(2):502-6. [pmid: 11171729].
7 Khand AU, Rankin AC, Martin W, et al. Carvedilol alone or in combination with digoxin for the management of atrial fibrillation in patients with heart failure?. J Am Coll Cardiol. 2003;42(11):1944-51. [pmid: 14662257].
8 Lindholm CJ, Fredholm O, Moller SJ, et al. Sinus rhythm maintenance following DC cardioversion of atrial fibrillation is not improved by temporary precardioversion treatment with oral verapamil. Heart. 2004;90(5):534-8. [pmid: 15084552].
9 Thomas SP, Guy D, Wallace E, et al. Rapid loading of sotalol or amiodarone for management of recent onset symptomatic atrial fibrillation: a randomized, digoxin-controlled trial. Am Heart J. 2004;147(1):E3. [pmid: 14691441].
10 Demircan C, Cikriklar HI, Engindeniz Z, et al. Comparison of the effectiveness of intravenous diltiazem and metoprolol in the management of rapid ventricular rate in atrial fibrillation. Emerg Med J. 2005;22(6):411-4. [pmid: 15911947].
11 Hemels ME, Van Noord T, Crijns HJ, et al. Verapamil versus digoxin and acute versus routine serial cardioversion for the improvement of rhythm control for persistent atrial fibrillation. J Am Coll Cardiol. 2006;48(5):1001-9. [pmid: 16949494].
12 Hofmann R, Steinwender C, Kammler J, et al. Effects of a high dose intravenous bolus amiodarone in patients with atrial fibrillation and a rapid ventricular rate. Int J Cardiol. 2006;110(1):27-32. [pmid: 16046015].
13 Tsuneda T, Yamashita T, Fukunami M, et al. Rate control and quality of life in patients with permanent atrial fibrillation: the Quality of Life and Atrial Fibrillation (QOLAF). Study Circ J. 2006;70(8):965-70. [pmid: 16864926].
14 Siu CW, Lau CP, Lee WL, et al. Intravenous diltiazem is superior to intravenous amiodarone or digoxin for achieving ventricular rate control in patients with acute uncomplicated atrial fibrillation. Crit Care Med. 2009;37(7):2174-9. quiz 80. [pmid: 19487941].
15 Van Gelder IC, Wyse DG, Chandler ML, et al. Does intensity of rate-control influence outcome in atrial fibrillation? An analysis of pooled data from the RACE and AFFIRM studies. Europace. 2006;8(11):935-42. [pmid: 16973686].
16 Groenveld HF, Crijns HJ, Rienstra M, et al. Does intensity of rate control influence outcome in persistent atrial fibrillation? Data of the RACE study. Am Heart J. 2009;158(5):785-91. [pmid: 19853699].
17 Van Gelder IC, Groenveld HF, Crijns HJ, et al. Lenient versus strict rate control in patients with atrial fibrillation. N Engl J Med. 2010;362(15):1363-73. [pmid: 20231232].
18 Groenveld HF, Crijns HJ, Van den Berg MP, et al. The effect of rate control on quality of life in patients with permanent atrial fibrillation: data from the RACE II (Rate Control Efficacy in Permanent Atrial Fibrillation II) study. J Am Coll Cardiol. 2011;58(17):1795-803. [pmid: 21996393].
19 Smit MD, Crijns HJ, Tijssen JG, et al. Effect of lenient versus strict rate control on cardiac remodeling in patients with atrial fibrillation data of the RACE II (RAte Control Efficacy in permanent atrial fibrillation II) study. J Am Coll Cardiol. 2011;58(9):942-9. [pmid: 21851883].
20 Levy T, Walker S, Mason M, et al. Importance of rate control or rate regulation for improving exercise capacity and quality of life in patients with permanent atrial fibrillation and normal left ventricular function: a randomised controlled study. Heart. 2001;85(2):171-8. [pmid: 11156667].
21 Weerasooriya R, Davis M, Powell A, et al. The Australian Intervention Randomized Control of Rate in Atrial Fibrillation Trial (AIRCRAFT). J Am Coll Cardiol. 2003;41(10):1697-702. [pmid: 12767649].
22 Lim KT, Davis MJ, Powell A, et al. Ablate and pace strategy for atrial fibrillation: long-term outcome of AIRCRAFT trial. Europace. 2007;9(7):498-505. [pmid: 17491103].
23 Kirkutis A, Poviliunas A, Griciene P, et al. Cardiac rate normalization in chronic atrial fibrillation: comparison of long-term efficacy of treatment with amiodarone versus AV node ablation and permanent His-bundle pacing. Proc West Pharmacol Soc. 2004;47:69-70. [pmid: 15633616].
24 Doshi RN, Daoud EG, Fellows C, et al. Left ventricular-based cardiac stimulation post AV nodal ablation evaluation (the PAVE study). J Cardiovasc Electrophysiol. 2005;16(11):1160-5. [pmid: 16302897].
25 Petrac D, Radic B, Radeljic V, et al. Ventricular pacing vs dual chamber pacing in patients with persistent atrial fibrillation after atrioventricular node ablation: open randomized study. Croat Med J. 2005;46(6):922-8. [pmid: 16342345].
26 Lee SH, Cheng JJ, Chen SA. A randomized, prospective comparison of anterior and posterior approaches to atrioventricular junction modification of medically refractory atrial fibrillation. Pacing Clin Electrophysiol. 2000;23(6):966-74. [pmid: 10879380].
27 Alp NJ, Rahman S, Bell JA, et al. Randomised comparison of antero-lateral versus antero-posterior paddle positions for DC cardioversion of persistent atrial fibrillation. Int J Cardiol. 2000;75(2-3):211-6. [pmid: 11077136].
28 Joglar JA, Hamdan MH, Ramaswamy K, et al. Initial energy for elective external cardioversion of persistent atrial fibrillation. Am J Cardiol. 2000;86(3):348-50. [pmid: 10922451].
29 Joseph AP, Ward MR. A prospective, randomized controlled trial comparing the efficacy and safety of sotalol, amiodarone, and digoxin for the reversion of new-onset atrial fibrillation. Ann Emerg Med. 2000;36(1):1-9. [pmid: 10874228].
30 Villani GQ, Piepoli MF, Terracciano C, et al. Effects of diltiazem pretreatment on direct-current cardioversion in patients with persistent atrial fibrillation: a single-blind, randomized, controlled study. Am Heart J. 2000;140(3):e12. [pmid: 10966543].
31 Ricard P, Levy S, Boccara G, et al. External cardioversion of atrial fibrillation: comparison of biphasic vs monophasic waveform shocks. Europace. 2001;3(2):96-9. [pmid: 11333061].
32 Van Noord T, Van Gelder IC, Tieleman RG, et al. VERDICT: the Verapamil versus Digoxin Cardioversion Trial: A randomized study on the role of calcium lowering for maintenance of sinus rhythm after cardioversion of persistent atrial fibrillation. J Cardiovasc Electrophysiol. 2001;12(7):766-9. [pmid: 11469424].
33 De Simone A, Turco P, De Matteis C, et al. Effect of verapamil on secondary cardioversion in patients with early atrial fibrillation recurrence after electrical cardioversion. Am J Cardiol. 2002;90(2):185-7. [pmid: 12106857].
34 Kirchhof P, Eckardt L, Loh P, et al. Anterior-posterior versus anterior-lateral electrode positions for external cardioversion of atrial fibrillation: a randomised trial. Lancet. 2002;360(9342):1275-9. [pmid: 12414201].
35 Page RL, Kerber RE, Russell JK, et al. Biphasic versus monophasic shock waveform for conversion of atrial fibrillation: the results of an international randomized, double-blind multicenter trial. J Am Coll Cardiol. 2002;39(12):1956-63. [pmid: 12084594].
36 Rashba EJ, Bouhouch R, MacMurdy KA, et al. Effect of shock polarity on the efficacy of transthoracic atrial defibrillation. Am Heart J. 2002;143(3):541-5. [pmid: 11868063].
37 Boos C, Thomas MD, Jones A, et al. Higher energy monophasic DC cardioversion for persistent atrial fibrillation: is it time to start at 360 joules?. Ann Noninvasive Electrocardiol. 2003;8(2):121-6. [pmid: 12848792].
38 Khaykin Y, Newman D, Kowalewski M, et al. Biphasic versus monophasic cardioversion in shock-resistant atrial fibrillation. J Cardiovasc Electrophysiol. 2003;14(8):868-72. [pmid: 12890051].
39 Manios EG, Mavrakis HE, Kanoupakis EM, et al. Effects of amiodarone and diltiazem on persistent atrial fibrillation conversion and recurrence rates: a randomized controlled study. Cardiovasc Drugs Ther. 2003;17(1):31-9. [pmid: 12843685].
40 Marinsek M, Larkin GL, Zohar P, et al. Efficacy and impact of monophasic versus biphasic countershocks for transthoracic cardioversion of persistent atrial fibrillation. Am J Cardiol. 2003;92(8):988-91. [pmid: 14556881].
41 Scholten M, Szili-Torok T, Klootwijk P, et al. Comparison of monophasic and biphasic shocks for transthoracic cardioversion of atrial fibrillation. Heart. 2003;89(9):1032-4. [pmid: 12923020].
42 Kanoupakis EM, Manios EG, Mavrakis HE, et al. Comparative effects of carvedilol and amiodarone on conversion and recurrence rates of persistent atrial fibrillation. Am J Cardiol. 2004;94(5):659-62. [pmid: 15342304].
43 Rashba EJ, Gold MR, Crawford FA, et al. Efficacy of transthoracic cardioversion of atrial fibrillation using a biphasic, truncated exponential shock waveform at variable initial shock energies. Am J Cardiol. 2004;94(12):1572-4. [pmid: 15589022].
44 Siaplaouras S, Buob A, Rotter C, et al. Impact of biphasic electrical cardioversion of atrial fibrillation on early recurrent atrial fibrillation and shock efficacy. J Cardiovasc Electrophysiol. 2004;15(8):895-7. [pmid: 15333081].
45 Alatawi F, Gurevitz O, White RD, et al. Prospective, randomized comparison of two biphasic waveforms for the efficacy and safety of transthoracic biphasic cardioversion of atrial fibrillation. Heart Rhythm. 2005;2(4):382-7. [pmid: 15851340].
46 Kirchhof P, Monnig G, Wasmer K, et al. A trial of self-adhesive patch electrodes and hand-held paddle electrodes for external cardioversion of atrial fibrillation (MOBIPAPA). Eur Heart J. 2005;26(13):1292-7. [pmid: 15734772].
47 Korantzopoulos P, Kolettis TM, Papathanasiou A, et al. Propafenone added to ibutilide increases conversion rates of persistent atrial fibrillation. Heart. 2006;92(5):631-4. [pmid: 16159973].
48 Siaplaouras S, Buob A, Rotter C, et al. Randomized comparison of anterolateral versus anteroposterior electrode position for biphasic external cardioversion of atrial fibrillation. Am Heart J. 2005;150(1):150-2. [pmid: 16084162].
49 Singh BN, Singh SN, Reda DJ, et al. Amiodarone versus sotalol for atrial fibrillation. N Engl J Med. 2005;352(18):1861-72. [pmid: 15872201].
50 Atwood JE, Myers JN, Tang XC, et al. Exercise capacity in atrial fibrillation: a substudy of the Sotalol-Amiodarone Atrial Fibrillation Efficacy Trial (SAFE-T). Am Heart J. 2007;153(4):566-72. [pmid: 17383295].
51 Batcher EL, Tang XC, Singh BN, et al. Thyroid function abnormalities during amiodarone therapy for persistent atrial fibrillation. Am J Med. 2007;120(10):880-5. [pmid: 17904459].
52 Singh SN, Tang XC, Reda D, et al. Systematic electrocardioversion for atrial fibrillation and role of antiarrhythmic drugs: a substudy of the SAFE-T trial. Heart Rhythm. 2009;6(2):152-5. [pmid: 19187902].
53 Ambler JJ, Deakin CD. A randomized controlled trial of efficacy and ST change following use of the Welch-Allyn MRL PIC biphasic waveform versus damped sine monophasic waveform for external DC cardioversion. Resuscitation. 2006;71(2):146-51. [pmid: 16987583].
54 Brazdzionyte J, Babarskiene RM, Stanaitiene G. Anterior-posterior versus anterior-lateral electrode position for biphasic cardioversion of atrial fibrillation. Medicina (Kaunas). 2006;42(12):994-8. [pmid: 17211107].
55 Mazzocca G, Corbucci G, Venturini E, et al. Is pretreatment with ibutilide useful for atrial fibrillation cardioversion when combined with biphasic shock?. J Cardiovasc Med (Hagerstown). 2006;7(2):124-8. [pmid: 16645372].
56 Redfearn DP, Skanes AC, Lane J, et al. Signal-averaged P wave reflects change in atrial electrophysiological substrate afforded by verapamil following cardioversion from atrial fibrillation. Pacing Clin Electrophysiol. 2006;29(10):1089-95. [pmid: 17038141].
57 Vijayalakshmi K, Whittaker VJ, Sutton A, et al. A randomized trial of prophylactic antiarrhythmic agents (amiodarone and sotalol) in patients with atrial fibrillation for whom direct current cardioversion is planned. Am Heart J. 2006;151(4):863 e1-6. [pmid: 16569550].
58 Boodhoo L, Mitchell AR, Bordoli G, et al. DC cardioversion of persistent atrial fibrillation: a comparison of two protocols. Int J Cardiol. 2007;114(1):16-21. [pmid: 16644036].
59 Hassan S, Slim AM, Kamalakannan D, et al. Conversion of atrial fibrillation to sinus rhythm during treatment with intravenous esmolol or diltiazem: a prospective, randomized comparison. J Cardiovasc Pharmacol Ther. 2007;12(3):227-31. [pmid: 17875950].
60 Kafkas NV, Patsilinakos SP, Mertzanos GA, et al. Conversion efficacy of intravenous ibutilide compared with intravenous amiodarone in patients with recent-onset atrial fibrillation and atrial flutter. Int J Cardiol. 2007;118(3):321-5. [pmid: 17049640].
61 Kawabata VS, Vianna CB, Moretti MA, et al. Monophasic versus biphasic waveform shocks for atrial fibrillation cardioversion in patients with concomitant amiodarone therapy. Europace. 2007;9(2):143-6. [pmid: 17272337].
62 Nergardh AK, Rosenqvist M, Nordlander R, et al. Maintenance of sinus rhythm with metoprolol CR initiated before cardioversion and repeated cardioversion of atrial fibrillation: a randomized double-blind placebo-controlled study. Eur Heart J. 2007;28(11):1351-7. [pmid: 17329409].
63 Glover BM, Walsh SJ, McCann CJ, et al. Biphasic energy selection for transthoracic cardioversion of atrial fibrillation. The BEST AF Trial. Heart. 2008;94(7):884-7. [pmid: 17591649].
64 Mortensen K, Risius T, Schwemer TF, et al. Biphasic versus monophasic shock for external cardioversion of atrial flutter: a prospective, randomized trial. Cardiology. 2008;111(1):57-62. [pmid: 18239394].
65 Fragakis N, Bikias A, Delithanasis I, et al. Acute beta-adrenoceptor blockade improves efficacy of ibutilide in conversion of atrial fibrillation with a rapid ventricular rate. Europace. 2009;11(1):70-4. [pmid: 18987127].
66 Balla I, Petrela E, Kondili A. Pharmacological conversion of recent atrial fibrillation: a randomized, placebo-controlled study of three antiarrhythmic drugs. Anadolu Kardiyol Derg. 2011;11(7):600-6. [pmid: 21911317].
67 Kochiadakis GE, Igoumenidis NE, Marketou ME, et al. Low dose amiodarone and sotalol in the treatment of recurrent, symptomatic atrial fibrillation: a comparative, placebo controlled study. Heart. 2000;84(3):251-7. [pmid: 10956284].
68 Kochiadakis GE, Marketou ME, Igoumenidis NE, et al. Amiodarone, sotalol, or propafenone in atrial fibrillation: which is preferred to maintain normal sinus rhythm?. Pacing Clin Electrophysiol. 2000;23(11 Pt 2):1883-7. [pmid: 11139949].
69 Roy D, Talajic M, Dorian P, et al. Amiodarone to prevent recurrence of atrial fibrillation. Canadian Trial of Atrial Fibrillation Investigators. N Engl J Med. 2000;342(13):913-20. [pmid: 10738049].
70 Dorian P, Mangat I. Quality of life variables in the selection of rate versus rhythm control in patients with atrial fibrillation: observations from the Canadian Trial of Atrial Fibrillation. Card Electrophysiol Rev. 2003;7(3):276-9. [pmid: 14739727].
71 Dorian P, Paquette M, Newman D, et al. Quality of life improves with treatment in the Canadian Trial of Atrial Fibrillation. Am Heart J. 2002;143(6):984-90. [pmid: 12075253].
72 Lumer GB, Roy D, Talajic M, et al. Amiodarone reduces procedures and costs related to atrial fibrillation in a controlled clinical trial. Eur Heart J. 2002;23(13):1050-6. [pmid: 12093058].
73 Bellandi F, Simonetti I, Leoncini M, et al. Long-term efficacy and safety of propafenone and sotalol for the maintenance of sinus rhythm after conversion of recurrent symptomatic atrial fibrillation. Am J Cardiol. 2001;88(6):640-5. [pmid: 11564387].
74 Plewan A, Lehmann G, Ndrepepa G, et al. Maintenance of sinus rhythm after electrical cardioversion of persistent atrial fibrillation; sotalol vs bisoprolol. Eur Heart J. 2001;22(16):1504-10. [pmid: 11482924].
75 Bertaglia E, D'Este D, Zerbo F, et al. Success of serial external electrical cardioversion of persistent atrial fibrillation in maintaining sinus rhythm; a randomized study. Eur Heart J. 2002;23(19):1522-8. [pmid: 12242072].
76 Deneke T, Khargi K, Grewe PH, et al. Efficacy of an additional MAZE procedure using cooled-tip radiofrequency ablation in patients with chronic atrial fibrillation and mitral valve disease. A randomized, prospective trial. Eur Heart J. 2002;23(7):558-66. [pmid: 11922646].
77 Khargi K, Deneke T, Haardt H, et al. Saline-irrigated, cooled-tip radiofrequency ablation is an effective technique to perform the maze procedure. Ann Thorac Surg. 2001;72(3):S1090-5. [pmid: 11570381].
78 Akpinar B, Guden M, Sagbas E, et al. Combined radiofrequency modified maze and mitral valve procedure through a port access approach: early and mid-term results. Eur J Cardiothorac Surg. 2003;24(2):223-30. [pmid: 12895612].
79 Anonymous. Maintenance of sinus rhythm in patients with atrial fibrillation: an AFFIRM substudy of the first antiarrhythmic drug. J Am Coll Cardiol. 2003;42(1):20-9. [pmid: 12849654].
80 De Simone A, De Pasquale M, De Matteis C, et al. VErapamil plus antiarrhythmic drugs reduce atrial fibrillation recurrences after an electrical cardioversion (VEPARAF Study). Eur Heart J. 2003;24(15):1425-9. [pmid: 12909071].
81 Jessurun ER, van Hemel NM, Defauw JJ, et al. A randomized study of combining maze surgery for atrial fibrillation with mitral valve surgery. J Cardiovasc Surg (Torino). 2003;44(1):9-18. [pmid: 12627066].
82 Katritsis DG, Panagiotakos DB, Karvouni E, et al. Comparison of effectiveness of carvedilol versus bisoprolol for maintenance of sinus rhythm after cardioversion of persistent atrial fibrillation. Am J Cardiol. 2003;92(9):1116-9. [pmid: 14583369].
83 Krittayaphong R, Raungrattanaamporn O, Bhuripanyo K, et al. A randomized clinical trial of the efficacy of radiofrequency catheter ablation and amiodarone in the treatment of symptomatic atrial fibrillation. J Med Assoc Thai. Suppl 1. 2003;86:S8-16. [pmid: 12866763].
84 Schuetz A, Schulze CJ, Sarvanakis KK, et al. Surgical treatment of permanent atrial fibrillation using microwave energy ablation: a prospective randomized clinical trial. Eur J Cardiothorac Surg. 2003;24(4):475-80. discussion 80. [pmid: 14500062].
85 Wazni O, Marrouche NF, Martin DO, et al. Randomized study comparing combined pulmonary vein-left atrial junction disconnection and cavotricuspid isthmus ablation versus pulmonary vein-left atrial junction disconnection alone in patients presenting with typical atrial flutter and atrial fibrillation. Circulation. 2003;108(20):2479-83. [pmid: 14610012].
86 de Lima GG, Kalil RA, Leiria TL, et al. Randomized study of surgery for patients with permanent atrial fibrillation as a result of mitral valve disease. Ann Thorac Surg. 2004;77(6):2089-94. discussion 94-5. [pmid: 15172273].
87 Haissaguerre M, Sanders P, Hocini M, et al. Changes in atrial fibrillation cycle length and inducibility during catheter ablation and their relation to outcome. Circulation. 2004;109(24):3007-13. [pmid: 15184286].
88 Katritsis DG, Ellenbogen KA, Panagiotakos DB, et al. Ablation of superior pulmonary veins compared to ablation of all four pulmonary veins. J Cardiovasc Electrophysiol. 2004;15(6):641-5. [pmid: 15175057].
89 Kochiadakis GE, Igoumenidis NE, Hamilos ME, et al. Sotalol versus propafenone for long-term maintenance of normal sinus rhythm in patients with recurrent symptomatic atrial fibrillation. Am J Cardiol. 2004;94(12):1563-6. [pmid: 15589019].
90 Kochiadakis GE, Igoumenidis NE, Hamilos MI, et al. Long-term maintenance of normal sinus rhythm in patients with current symptomatic atrial fibrillation: amiodarone vs propafenone, both in low doses. Chest. 2004;125(2):377-83. [pmid: 14769712].
91 Oral H, Chugh A, Lemola K, et al. Noninducibility of atrial fibrillation as an end point of left atrial circumferential ablation for paroxysmal atrial fibrillation: a randomized study. Circulation. 2004;110(18):2797-801. [pmid: 15505091].
92 Abreu Filho CA, Lisboa LA, Dallan LA, et al. Effectiveness of the maze procedure using cooled-tip radiofrequency ablation in patients with permanent atrial fibrillation and rheumatic mitral valve disease. Circulation. 2005;112(9 Suppl):I20-5. [pmid: 16159816].
93 Doukas G, Samani NJ, Alexiou C, et al. Left atrial radiofrequency ablation during mitral valve surgery for continuous atrial fibrillation: a randomized controlled trial. JAMA. 2005;294(18):2323-9. [pmid: 16278360].
94 Fassini G, Riva S, Chiodelli R, et al. Left mitral isthmus ablation associated with PV Isolation: long-term results of a prospective randomized study. J Cardiovasc Electrophysiol. 2005;16(11):1150-6. [pmid: 16302895].
95 Hocini M, Jais P, Sanders P, et al. Techniques, evaluation, and consequences of linear block at the left atrial roof in paroxysmal atrial fibrillation: a prospective randomized study. Circulation. 2005;112(24):3688-96. [pmid: 16344401].
96 Karch MR, Zrenner B, Deisenhofer I, et al. Freedom from atrial tachyarrhythmias after catheter ablation of atrial fibrillation: a randomized comparison between 2 current ablation strategies. Circulation. 2005;111(22):2875-80. [pmid: 15927974].
97 Oral H, Chugh A, Good E, et al. Randomized comparison of encircling and nonencircling left atrial ablation for chronic atrial fibrillation. Heart Rhythm. 2005;2(11):1165-72. [pmid: 16253904].
98 Wazni OM, Marrouche NF, Martin DO, et al. Radiofrequency ablation vs antiarrhythmic drugs as first-line treatment of symptomatic atrial fibrillation: a randomized trial. JAMA. 2005;293(21):2634-40. [pmid: 15928285].
99 Calo L, Lamberti F, Loricchio ML, et al. Left atrial ablation versus biatrial ablation for persistent and permanent atrial fibrillation: a prospective and randomized study. J Am Coll Cardiol. 2006;47(12):2504-12. [pmid: 16781381].
100 Dixit S, Gerstenfeld EP, Callans DJ, et al. Comparison of cool tip versus 8-mm tip catheter in achieving electrical isolation of pulmonary veins for long-term control of atrial fibrillation: a prospective randomized pilot study. J Cardiovasc Electrophysiol. 2006;17(10):1074-9. [pmid: 16879626].
101 Liu X, Long D, Dong J, et al. Is circumferential pulmonary vein isolation preferable to stepwise segmental pulmonary vein isolation for patients with paroxysmal atrial fibrillation?. Circ J. 2006;70(11):1392-7. [pmid: 17062959].
102 Nilsson B, Chen X, Pehrson S, et al. Recurrence of pulmonary vein conduction and atrial fibrillation after pulmonary vein isolation for atrial fibrillation: a randomized trial of the ostial versus the extraostial ablation strategy. Am Heart J. 2006;152(3):537 e1-8. [pmid: 16923426].
103 Oral H, Pappone C, Chugh A, et al. Circumferential pulmonary-vein ablation for chronic atrial fibrillation. N Engl J Med. 2006;354(9):934-41. [pmid: 16510747].
104 Pappone C, Augello G, Sala S, et al. A randomized trial of circumferential pulmonary vein ablation versus antiarrhythmic drug therapy in paroxysmal atrial fibrillation: the APAF Study. J Am Coll Cardiol. 2006;48(11):2340-7. [pmid: 17161267].
105 Pappone C, Vicedomini G, Giuseppe A, et al. Radiofrequency Catheter Ablation and Antiarrhythmic Drug Therapy: A Prospective, Randomized 4-Year Follow-Up Trial - The APAF Study. Circ Arrhythm Electrophysiol. 2011. [pmid: 21946315].
106 Sheikh I, Krum D, Cooley R, et al. Pulmonary vein isolation and linear lesions in atrial fibrillation ablation. J Interv Card Electrophysiol. 2006;17(2):103-9. [pmid: 17318445].
107 Stabile G, Bertaglia E, Senatore G, et al. Catheter ablation treatment in patients with drug-refractory atrial fibrillation: a prospective, multi-centre, randomized, controlled study (Catheter Ablation For The Cure Of Atrial Fibrillation Study). Eur Heart J. 2006;27(2):216-21. [pmid: 16214831].
108 Willems S, Klemm H, Rostock T, et al. Substrate modification combined with pulmonary vein isolation improves outcome of catheter ablation in patients with persistent atrial fibrillation: a prospective randomized comparison. Eur Heart J. 2006;27(23):2871-8. [pmid: 16782716].
109 Arentz T, Weber R, Burkle G, et al. Small or large isolation areas around the pulmonary veins for the treatment of atrial fibrillation? Results from a prospective randomized study. Circulation. 2007;115(24):3057-63. [pmid: 17562956].
110 Blomstrom-Lundqvist C, Johansson B, Berglin E, et al. A randomized double-blind study of epicardial left atrial cryoablation for permanent atrial fibrillation in patients undergoing mitral valve surgery: the SWEDish Multicentre Atrial Fibrillation study (SWEDMAF). Eur Heart J. 2007;28(23):2902-8. [pmid: 17984136].
111 Turco P, De Simone A, La Rocca V, et al. Antiarrhythmic drug therapy after radiofrequency catheter ablation in patients with atrial fibrillation. Pacing Clin Electrophysiol. Suppl 1. 2007;30:S112-5. [pmid: 17302684].
112 Di Biase L, Elayi CS, Fahmy TS, et al. Atrial fibrillation ablation strategies for paroxysmal patients: randomized comparison between different techniques. Circ Arrhythm Electrophysiol. 2009;2(2):113-9. [pmid: 19808455].
113 Dixit S, Gerstenfeld EP, Ratcliffe SJ, et al. Single procedure efficacy of isolating all versus arrhythmogenic pulmonary veins on long-term control of atrial fibrillation: a prospective randomized study. Heart Rhythm. 2008;5(2):174-81. [pmid: 18242535].
114 Elayi CS, Verma A, Di Biase L, et al. Ablation for longstanding permanent atrial fibrillation: results from a randomized study comparing three different strategies. Heart Rhythm. 2008;5(12):1658-64. [pmid: 19084800].
115 Fiala M, Chovancik J, Nevralova R, et al. Pulmonary vein isolation using segmental versus electroanatomical circumferential ablation for paroxysmal atrial fibrillation: over 3-year results of a prospective randomized study. J Interv Card Electrophysiol. 2008;22(1):13-21. [pmid: 18418704].
116 Gaita F, Caponi D, Scaglione M, et al. Long-term clinical results of 2 different ablation strategies in patients with paroxysmal and persistent atrial fibrillation. Circ Arrhythm Electrophysiol. 2008;1(4):269-75. [pmid: 19808418].
117 Jais P, Cauchemez B, Macle L, et al. Catheter ablation versus antiarrhythmic drugs for atrial fibrillation: the A4 study. Circulation. 2008;118(24):2498-505. [pmid: 19029470].
118 Oral H, Chugh A, Good E, et al. Randomized evaluation of right atrial ablation after left atrial ablation of complex fractionated atrial electrograms for long-lasting persistent atrial fibrillation. Circ Arrhythm Electrophysiol. 2008;1(1):6-13. [pmid: 19808388].
119 Srivastava V, Kumar S, Javali S, et al. Efficacy of three different ablative procedures to treat atrial fibrillation in patients with valvular heart disease: a randomised trial. Heart Lung Circ. 2008;17(3):232-40. [pmid: 18242137].
120 Wang XH, Liu X, Sun YM, et al. Pulmonary vein isolation combined with superior vena cava isolation for atrial fibrillation ablation: a prospective randomized study. Europace. 2008;10(5):600-5. [pmid: 18442966].
121 Albrecht A, Kalil RA, Schuch L, et al. Randomized study of surgical isolation of the pulmonary veins for correction of permanent atrial fibrillation associated with mitral valve disease. J Thorac Cardiovasc Surg. 2009;138(2):454-9. [pmid: 19619795].
122 Chevalier P, Leizorovicz A, Maureira P, et al. Left atrial radiofrequency ablation during mitral valve surgery: a prospective randomized multicentre study (SAFIR). Arch Cardiovasc Dis. 2009;102(11):769-75. [pmid: 19944393].
123 Deisenhofer I, Estner H, Reents T, et al. Does electrogram guided substrate ablation add to the success of pulmonary vein isolation in patients with paroxysmal atrial fibrillation? A prospective, randomized study. J Cardiovasc Electrophysiol. 2009;20(5):514-21. [pmid: 19207759].
124 Forleo GB, Mantica M, De Luca L, et al. Catheter ablation of atrial fibrillation in patients with diabetes mellitus type 2: results from a randomized study comparing pulmonary vein isolation versus antiarrhythmic drug therapy. J Cardiovasc Electrophysiol. 2009;20(1):22-8. [pmid: 18775050].
125 Khaykin Y, Skanes A, Champagne J, et al. A randomized controlled trial of the efficacy and safety of electroanatomic circumferential pulmonary vein ablation supplemented by ablation of complex fractionated atrial electrograms versus potential-guided pulmonary vein antrum isolation guided by intracardiac ultrasound. Circ Arrhythm Electrophysiol. 2009;2(5):481-7. [pmid: 19843915].
126 Oral H, Chugh A, Yoshida K, et al. A randomized assessment of the incremental role of ablation of complex fractionated atrial electrograms after antral pulmonary vein isolation for long-lasting persistent atrial fibrillation. J Am Coll Cardiol. 2009;53(9):782-9. [pmid: 19245970].
127 Pontoppidan J, Nielsen JC, Poulsen SH, et al. Prophylactic cavotricuspid isthmus block during atrial fibrillation ablation in patients without atrial flutter: a randomised controlled trial. Heart. 2009;95(12):994-9. [pmid: 19261602].
128 Roux JF, Zado E, Callans DJ, et al. Antiarrhythmics After Ablation of Atrial Fibrillation (5A Study). Circulation. 2009;120(12):1036-40. [pmid: 19738139].
129 Leong-Sit P, Roux JF, Zado E, et al. Antiarrhythmics after ablation of atrial fibrillation (5A Study): six-month follow-up study. Circ Arrhythm Electrophysiol. 2011;4(1):11-4. [pmid: 21076158].
130 Tamborero D, Mont L, Berruezo A, et al. Left atrial posterior wall isolation does not improve the outcome of circumferential pulmonary vein ablation for atrial fibrillation: a prospective randomized study. Circ Arrhythm Electrophysiol. 2009;2(1):35-40. [pmid: 19808442].
131 von Oppell UO, Masani N, O'Callaghan P, et al. Mitral valve surgery plus concomitant atrial fibrillation ablation is superior to mitral valve surgery alone with an intensive rhythm control strategy. Eur J Cardiothorac Surg. 2009;35(4):641-50. [pmid: 19233678].
132 Wang J, Meng X, Li H, et al. Prospective randomized comparison of left atrial and biatrial radiofrequency ablation in the treatment of atrial fibrillation. Eur J Cardiothorac Surg. 2009;35(1):116-22. [pmid: 18952450].
133 Bulava A, Hanis J, Sitek D, et al. Catheter ablation for paroxysmal atrial fibrillation: a randomized comparison between multielectrode catheter and point-by-point ablation. Pacing Clin Electrophysiol. 2010;33(9):1039-46. [pmid: 20528997].
134 Chen M, Yang B, Chen H, et al. Randomized comparison between pulmonary vein antral isolation versus complex fractionated electrogram ablation for paroxysmal atrial fibrillation. J Cardiovasc Electrophysiol. 2011;22(9):973-81. [pmid: 21539635].
135 Corrado A, Bonso A, Madalosso M, et al. Impact of systematic isolation of superior vena cava in addition to pulmonary vein antrum isolation on the outcome of paroxysmal, persistent, and permanent atrial fibrillation ablation: results from a randomized study. J Cardiovasc Electrophysiol. 2010;21(1):1-5. [pmid: 19732237].
136 Kim YH, Lim HE, Pak HN, et al. Role of residual potentials inside circumferential pulmonary veins ablation lines in the recurrence of paroxysmal atrial fibrillation. J Cardiovasc Electrophysiol. 2010;21(9):959-65. [pmid: 20367660].
137 Knaut M, Kolberg S, Brose S, et al. Epicardial microwave ablation of permanent atrial fibrillation during a coronary bypass and/or aortic valve operation: Prospective, randomised, controlled, mono-centric study. Appl Cardiopulm Pathophysiol. 2010;14(4):220-8.
138 Liu X, Tan HW, Wang XH, et al. Efficacy of catheter ablation and surgical CryoMaze procedure in patients with long-lasting persistent atrial fibrillation and rheumatic heart disease: a randomized trial. Eur Heart J. 2010;31(21):2633-41. [pmid: 20573636].
139 Le Heuzey JY, De Ferrari GM, Radzik D, et al. A short-term, randomized, double-blind, parallel-group study to evaluate the efficacy and safety of dronedarone versus amiodarone in patients with persistent atrial fibrillation: the DIONYSOS study. J Cardiovasc Electrophysiol. 2010;21(6):597-605. [pmid: 20384650].
140 Pires LM, Leiria TL, de Lima GG, et al. Comparison of surgical cut and sew versus radiofrequency pulmonary veins isolation for chronic permanent atrial fibrillation: a randomized study. Pacing Clin Electrophysiol. 2010;33(10):1249-57. [pmid: 20546155].
141 Sawhney N, Anousheh R, Chen W, et al. Circumferential pulmonary vein ablation with additional linear ablation results in an increased incidence of left atrial flutter compared with segmental pulmonary vein isolation as an initial approach to ablation of paroxysmal atrial fibrillation. Circ Arrhythm Electrophysiol. 2010;3(3):243-8. [pmid: 20339034].
142 Wilber DJ, Pappone C, Neuzil P, et al. Comparison of antiarrhythmic drug therapy and radiofrequency catheter ablation in patients with paroxysmal atrial fibrillation: a randomized controlled trial. JAMA. 2010;303(4):333-40. [pmid: 20103757].
143 Reynolds MR, Walczak J, White SA, et al. Improvements in symptoms and quality of life in patients with paroxysmal atrial fibrillation treated with radiofrequency catheter ablation versus antiarrhythmic drugs. Circ Cardiovasc Qual Outcomes. 2010;3(6):615-23. [pmid: 20940250].
144 Van Breugel HN, Nieman FH, Accord RE, et al. A prospective randomized multicenter comparison on health-related quality of life: the value of add-on arrhythmia surgery in patients with paroxysmal, permanent or persistent atrial fibrillation undergoing valvular and/or coronary bypass surgery. J Cardiovasc Electrophysiol. 2010;21(5):511-20. [pmid: 19925605].
145 Verma A, Mantovan R, Macle L, et al. Substrate and Trigger Ablation for Reduction of Atrial Fibrillation (STAR AF): a randomized, multicentre, international trial. Eur Heart J. 2010;31(11):1344-56. [pmid: 20215126].
146 Bittner A, Monnig G, Zellerhoff S, et al. Randomized study comparing duty-cycled bipolar and unipolar radiofrequency with point-by-point ablation in pulmonary vein isolation. Heart Rhythm. 2011;8(9):1383-90. [pmid: 21457793].
147 Dixit S, Marchlinski FE, Lin D, et al. Randomized ablation strategies for the treatment of persistent atrial fibrillation: RASTA study. Circ Arrhythm Electrophysiol. 2012;5(2):287-94. [pmid: 22139886].
148 Boersma LV, Castella M, van Boven W, et al. Atrial fibrillation catheter ablation versus surgical ablation treatment (FAST): a 2-center randomized clinical trial. Circulation. 2012;125(1):23-30. [pmid: 22082673].
149 Gavin AR, Singleton CB, Bowyer J, et al. Pulmonary venous isolation versus additional substrate modification as treatment for paroxysmal atrial fibrillation. J Interv Card Electrophysiol. 2012;33(1):101-7. [pmid: 21938518].
150 Mun HS, Joung B, Shim J, et al. Does additional linear ablation after circumferential pulmonary vein isolation improve clinical outcome in patients with paroxysmal atrial fibrillation? Prospective randomised study. Heart. 2012;98(6):480-4. [pmid: 22285969].
151 Hohnloser SH, Kuck KH, Lilienthal J. Rhythm or rate control in atrial fibrillation—Pharmacological Intervention in Atrial Fibrillation (PIAF): a randomised trial. Lancet. 2000;356(9244):1789-94. [pmid: 11117910].
152 Gronefeld GC, Lilienthal J, Kuck KH, et al. Impact of rate versus rhythm control on quality of life in patients with persistent atrial fibrillation. Results from a prospective randomized study. Eur Heart J. 2003;24(15):1430-6. [pmid: 12909072].
153 Brignole M, Menozzi C, Gasparini M, et al. An evaluation of the strategy of maintenance of sinus rhythm by antiarrhythmic drug therapy after ablation and pacing therapy in patients with paroxysmal atrial fibrillation. Eur Heart J. 2002;23(11):892-900. [pmid: 12042011].
154 Van Gelder IC, Hagens VE, Bosker HA, et al. A comparison of rate control and rhythm control in patients with recurrent persistent atrial fibrillation. N Engl J Med. 2002;347(23):1834-40. [pmid: 12466507].
155 Hagens VE, Ranchor AV, Van Sonderen E, et al. Effect of rate or rhythm control on quality of life in persistent atrial fibrillation. Results from the Rate Control Versus Electrical Cardioversion (RACE) Study. J Am Coll Cardiol. 2004;43(2):241-7. [pmid: 14736444].
156 Hagens VE, Rienstra M, Van Veldhuisen DJ, et al. Determinants of sudden cardiac death in patients with persistent atrial fibrillation in the rate control versus electrical cardioversion (RACE) study. Am J Cardiol. 2006;98(7):929-32. [pmid: 16996876].
157 Hagens VE, Van Veldhuisen DJ, Kamp O, et al. Effect of rate and rhythm control on left ventricular function and cardiac dimensions in patients with persistent atrial fibrillation: results from the RAte Control versus Electrical Cardioversion for Persistent Atrial Fibrillation (RACE) study. Heart Rhythm. 2005;2(1):19-24. [pmid: 15851259].
158 Rienstra M, Van Veldhuisen DJ, Crijns HJ, et al. Enhanced cardiovascular morbidity and mortality during rhythm control treatment in persistent atrial fibrillation in hypertensives: data of the RACE study. Eur Heart J. 2007;28(6):741-51. [pmid: 17272359].
159 Rienstra M, Van Veldhuisen DJ, Hagens VE, et al. Gender-related differences in rhythm control treatment in persistent atrial fibrillation: data of the Rate Control Versus Electrical Cardioversion (RACE) study. J Am Coll Cardiol. 2005;46(7):1298-306. [pmid: 16198847].
160 Wyse DG, Waldo AL, DiMarco JP, et al. A comparison of rate control and rhythm control in patients with atrial fibrillation. N Engl J Med. 2002;347(23):1825-33. [pmid: 12466506].
161 Bush D, Martin LW, Leman R, et al. Atrial fibrillation among African Americans, Hispanics and Caucasians: clinical features and outcomes from the AFFIRM trial. J Natl Med Assoc. 2006;98(3):330-9. [pmid: 16573295].
162 Chung MK, Shemanski L, Sherman DG, et al. Functional status in rate- versus rhythm-control strategies for atrial fibrillation: results of the Atrial Fibrillation Follow-Up Investigation of Rhythm Management (AFFIRM) Functional Status Substudy. J Am Coll Cardiol. 2005;46(10):1891-9. [pmid: 16286177].
163 Curtis AB, Gersh BJ, Corley SD, et al. Clinical factors that influence response to treatment strategies in atrial fibrillation: the Atrial Fibrillation Follow-up Investigation of Rhythm Management (AFFIRM) study. Am Heart J. 2005;149(4):645-9. [pmid: 15990747].
164 Guglin M, Chen R, Curtis AB. Sinus rhythm is associated with fewer heart failure symptoms: insights from the AFFIRM trial. Heart Rhythm. 2010;7(5):596-601. [pmid: 20159046].
165 Jenkins LS, Brodsky M, Schron E, et al. Quality of life in atrial fibrillation: the Atrial Fibrillation Follow-up Investigation of Rhythm Management (AFFIRM) study. Am Heart J. 2005;149(1):112-20. [pmid: 15660042].
166 Sherman DG, Kim SG, Boop BS, et al. Occurrence and characteristics of stroke events in the Atrial Fibrillation Follow-up Investigation of Sinus Rhythm Management (AFFIRM) study. Arch Intern Med. 2005;165(10):1185-91. [pmid: 15911734].
167 Steinberg JS, Sadaniantz A, Kron J, et al. Analysis of cause-specific mortality in the Atrial Fibrillation Follow-up Investigation of Rhythm Management (AFFIRM) study. Circulation. 2004;109(16):1973-80. [pmid: 15051639].
168 Carlsson J, Miketic S, Windeler J, et al. Randomized trial of rate-control versus rhythm-control in persistent atrial fibrillation: the Strategies of Treatment of Atrial Fibrillation (STAF) study. J Am Coll Cardiol. 2003;41(10):1690-6. [pmid: 12767648].
169 Carlsson J, Boos C. Confounding factors in rate versus rhythm control trials in patients with atrial fibrillation: lessons from the strategies of treatment of atrial fibrillation (STAF) pilot study. Card Electrophysiol Rev. 2003;7(2):122-6. [pmid: 14618034].
170 Okcun B, Yigit Z, Arat A, et al. Comparison of rate and rhythm control in patients with atrial fibrillation and nonischemic heart failure. Jpn Heart J. 2004;45(4):591-601. [pmid: 15353870].
171 Opolski G, Torbicki A, Kosior DA, et al. Rate control vs rhythm control in patients with nonvalvular persistent atrial fibrillation: the results of the Polish How to Treat Chronic Atrial Fibrillation (HOT CAFE). Study Chest. 2004;126(2):476-86. [pmid: 15302734].
172 Opolski G, Torbicki A, Kosior D, et al. Rhythm control versus rate control in patients with persistent atrial fibrillation. Results of the HOT CAFE Polish Study. Kardiol Pol. 2003;59(7):1-16. discussion 5-. [pmid: 14560344].
173 Pietrasik A, Kosior DA, Niewada M, et al. The cost comparison of rhythm and rate control strategies in persistent atrial fibrillation. Int J Cardiol. 2007;118(1):21-7. [pmid: 17055081].
174 Szulc M, Kosior DA, Jasik M, et al. The effect of rate versus rhythm control strategy on the left ventricular function in patients with persistent atrial fibrillation: Results of one year follow-up. Folia Cardiol. 2006;13(4):331-7.
175 Vora A, Karnad D, Goyal V, et al. Control of heart rate versus rhythm in rheumatic atrial fibrillation: a randomized study. J Cardiovasc Pharmacol Ther. 2004;9(2):65-73. [pmid: 15309242].
176 Vora A, Karnad D, Goyal V, et al. Control of rate versus rhythm in rheumatic atrial fibrillation: a randomized study. Indian Heart J. 2004;56(2):110-6. [pmid: 15377131].
177 Khan MN, Jais P, Cummings J, et al. Pulmonary-vein isolation for atrial fibrillation in patients with heart failure. N Engl J Med. 2008;359(17):1778-85. [pmid: 18946063].
178 Yildiz A, Yigit Z, Okcun B, et al. Comparison of rate and rhythm control in hypertension patients with atrial fibrillation. Circ J. 2008;72(5):705-8. [pmid: 18441447].
179 Shelton RJ, Clark AL, Goode K, et al. A randomised, controlled study of rate versus rhythm control in patients with chronic atrial fibrillation and heart failure: (CAFE-II Study). Heart. 2009;95(11):924-30. [pmid: 19282313].
180 Talajic M, Khairy P, Levesque S, et al. Maintenance of sinus rhythm and survival in patients with heart failure and atrial fibrillation. J Am Coll Cardiol. 2010;55(17):1796-802. [pmid: 20413028].
181 Roy D, Talajic M, Nattel S, et al. Rhythm control versus rate control for atrial fibrillation and heart failure. N Engl J Med. 2008;358(25):2667-77. [pmid: 18565859].
182 MacDonald MR, Connelly DT, Hawkins NM, et al. Radiofrequency ablation for persistent atrial fibrillation in patients with advanced heart failure and severe left ventricular systolic dysfunction: a randomised controlled trial. Heart. 2011;97(9):740-7. [pmid: 21051458].