# List of Excluded Studies

All studies listed below were reviewed in their full-text version and excluded for the reasons cited. Reasons for exclusion signify only the usefulness of the articles for this study and are not intended as criticisms of the articles.

## Not Available in English

Hohnloser S, Crijns H, van Eickels M, et al. Effect of dronedarone on cardiovascular events in atrial fibrillation. Rev Port Cardiol. 2009;28(3):345-347.
Niu F, Huang CX, Jiang H, et al. Effects of amiodarone versus sotalol in treatment of atrial fibrillation: a random controlled clinical study. Zhonghua Yi Xue Za Zhi. 2006;86(2):121-3. [pmid: 16620720].
Romano S, Fattore L, Toscano G, et al. Intravenous treatment with propafenone and flecainide in recent-onset atrial fibrillation. Ital Heart J Suppl. 2001;2(1):41-45. [pmid: 11216083].
Torp-Pedersen CT, Moller M, Bloch-Thomsen PE, et al. Dofetilide to patients with heart failure and left ventricular dysfunction. Ugeskrift for Laeger. 2000;162(44):5948-53. [pmid: 11094565].

## Not a Full Publication, Not Original Data, or Not Peer-Reviewed Literature Published 2000 to Present

Anonymous. Atrial fibrillation: strict heart rate control provides no advantage. Prescrire Int. 2011;20(120):246. [pmid: 21970095].
Bagherzadeh AA, Moghaddam M, Moshkani Farahani M. Effects of atrioventricular junctional radiofrequency ablation in patients with chronic atrial fibrillationwho are candidates for cardiac resynchronization therapy. J Cardiovasc Electrophysiol. 2011;22:S100-S101.
Bai R, Di Biase L, Mohanty P, et al. Proven isolation of the pulmonary vein versus extended PV antrum and posterior wall isolation in patients with long standing persistent atrial fibrillation. Heart Rhythm. 2012;9(5 SUPPL. 1):S199-S200.
Bai R, Di Biase L, Mohanty P, et al. Catheter ablation of paroxysmal or persistent atrial fibrillation in patient with previous mitral valve surgery: Outcome after documented pulmonary vein isolation versus extended pulmonary vein antrum isolation. Heart Rhythm. 2012;9(5 SUPPL. 1):S199.
Bastani H, Drca N, Insulander P, et al. CRAFT - A prospective randomised comparison of cryothermal and radiofrequency ablation as atrial flutter therapy. Eur Heart J. 2011;32:1108.
Biase LD, Santangeli P, Mohanty P, et al. Empirical left atrial appendage isolation improves the success rate of catheter ablation of long standing persistent atrial fibrillation after a single procedure: Results from a prospective multicenter study. Heart Rhythm. 2012;9(5 SUPPL. 1):S126.
Boersma L. Atrial fibrillation catheter ablation vs. surgical ablation treatment (FAST): A multi-centre randomized clinical trial. European Heart Journal. 2012;33(1):142.
Boersma LVA, Calkins H, Rusch L, et al., et al. Phased radiofrequency ablation is superior to medical therapy for the treatment of persistent atrial fibrillation. Heart Rhythm. 2012;9(5 SUPPL. 1):S491.
Boriani G, Iacopino S, Landolina M, et al. Incidence and clinical relevance of uncontrolled ventricular rate during atrial fibrillation in heart failure patients treated with cardiac resynchronization therapy. Eur Heart J. 2011;32:147.
Catherwood E, Teng MP, Melby DP. Cost-effectiveness of current management strategies in atrial fibrillation. Cardiac Electrophysiology Rev. 2001;5(2-3):254-262.
Chevalier P, Durand-Dubief A, Burri H, et al. Amiodarane has a slower onset of action than class Ic drugs in converting atrial fibrillation to sinus rhythm. Evidence-based Cardiovasc Med. 2003;7(3):117-118.
Chiaranda G, Cavarra ML, D'Angelo G, et al. Paroxysmal atrial fibrillation new onset or persistent: Is antiarrhythmic prophylaxis necessary?. J Cardiovasc Electrophysiol. 2011;22:S5-S6.
Deakin CD, Connelly S, Yuen B. A prospective randomized study of the efficacy of rectilinear and truncated exponential biphasic waveforms in the elective cardioversion of atrial fibrillation. Circulation. 2011;124(21):2011-11.
DeSimone KL. Is a single oral dose of amiodarone safe and effective in converting new-onset atrial fibrillation (AF) to sinus rhythm?. J Fam Pract. 2000;49(6):493-4. [pmid: 10923543].
Di Biase L, Santangelli P, Mohanty P, et al. Preliminary results from the speculate randomized study: Effect of amiodarone on the procedure outcome in long-standing persistent atrial fibrillation undergoing extended pulmonary vein antrum isolation. Circulation. 2011;124(21):2011-11.
Duncan E, Liew R, Goromonzi F, et al. A randomised controlled trial of catheter ablation of atrial fibrillation comparing manual and robotic navigation: Experience with the hansen robotic system. Heart. 2010;96:A77.
Duncan ER, Hunter RJ, Tayebjee M, et al. A randomized trial of cryoablation vs. radiofrequency ablation vs. both for paroxysmal atrial fibrillation. Europace. 2011;13:iv3.
Duray GZ, Torp-Pedersen C, Connolly SJ, et al. Effects of dronedarone on clinical outcomes in patients with lone atrial fibrillation: pooled post hoc analysis from the ATHENA/EURIDIS/ADONIS studies. J Cardiovasc Electrophysiol. 2011;22(7):770-6. [pmid: 21288278].
Dyrda K, Roy D, Leduc H, et al. Adapting treatment strategies in patients with atrial fibrillation and congestive heart failure: An AF-CHF substudy. Heart Rhythm. 2012;9(5 SUPPL. 1):S264.
Dyrda K, Roy D, Leduc H, et al. Adapting treatment strategies in patients with atrial fibrillation and congestive heart failure: An AF-CHF substudy. Journal of Interventional Cardiac Electrophysiology. 2012;33(3):313.
England J, Lewandowski M, Huang S, et al. Three sisters study: Atrial pacing and beta blockade for the suppression of atrial fibrillation: Six year follow-up. Heart Lung and Circulation. 2011;20:S110-S111.
Fernandez Lozano I, Mitroi C, Toquero Ramos J, et al. Cardiac resynchronization therapy and atrial fibrillation: Three leads better than two. Europace. 2011;13(3):2011-06.
Fiala M, Wichterle D, Sknouril L, et al. Subgroup analysis of benefit from bi-atrial ablation for long-standing persistent atrial fibrillation. Europace. 2011;13(3):2011-06.
Fichtner S, Estner H, Buchner M, et al. To isolate or not to isolate: A prospective randomized study comparing standard pulmonary vein isolation vs. arrhythmogenic vein isolation in paroxysmal atrial fibrillation. Journal of Interventional Cardiac Electrophysiology. 2012;33(3):338-339.
Fichtner S, Estner HL, Buchner M, et al. To isolate or not to isolate: A prospective randomized study comparing standard pulmonary vein isolation vs. arrhythmogenic vein isolation in paroxysmal atrial fibrillation. Eur Heart J. 2011;32:1111.
Forney AJ, Schooff M. Is either sotalol or amiodarone more effective than digoxin for converting patients with new-onset atrial fibrillation (AF) to sinus rhythm within 48 hours?. J Fam Pract. 2000;49(11):982. [pmid: 11093561].
Fromm C, Suau S, Cohen V, et al. Comparison of diltiazem and metoprolol in the management of atrial fibrillation or flutter with rapid ventricular rate in the emergency department: A prospective, Randomized, Double-blind Trial. Academic Emergency Medicine. 2011;18(5):S235.
Gramley F, Koellensperger E, Kettering K. Catheter ablation of atrial fibrillation combined with dronedarone as a new hybrid therapy option. Internist. SUPPL. 1. 2012;53:83-84.
Gramley F, Koellensperger E, Munzel T, et al. Dronedarone therapy after catheter ablation of atrial fibrillation: a new hybrid therapy option. Europace. 2011;13(3):2011-06.
Groenveld HF, Crijns HJG, Hillege HL, et al. Rate control efficacy in permanent atrial fibrillation: A comparison between true lenient versus true strict rate control. More data from the RACE II study. Eur Heart J. 2011;32:624.
Hagens VE, Vermeulen KM, Ten Vergert EM, et al. Rate control was more cost effective than rhythm control in persistent atrial fibrillation. Evidence-Based Medicine. 2005;10(2):59.
Hohnloser SH, Kuch KH, Lilienthal J. Rate and rhythm control showed simular symptom improvement in atrial fibrillation. Evidence-Based Medicine. 2001;6(4):113.
Horduna IS, Roy D, Frasure-Smith N, et al. Quality of life and functional capacity in patients with atrial fibrillation and congestive heart failure. Heart Rhythm. 2012;9(5 SUPPL. 1):S460.
Hunter RJ, Berriman TJ, Diab I, et al. A randomized Controlled Trial of catheter ablation vs. Medical Treatment of Atrial Fibrillation in heart failure (the CAMTAF trial). Europace. 2011;13:iv3.
Hunter RJ, Berriman TJ, Diab I, et al. A randomised controlled trial of catheter ablation versus medical treatment of atrial fibrillation in heart failure (the camtaf trial). PACE - Pacing and Clinical Electrophysiology. 2011;34(11):1367.
Jais P, Cauchemez B, Macle L, et al. LBA-6565: Atrial fibrillation ablation vs antiarrhythmic drugs: A multicenter randomized trial. Heart Rhythm. 2006;3(9):1126.
Lavanga S, Nassiacos D. Repeated intravenous boluses of flecainide for acute atrial fibrillation termination: A randomized singleblind regimen controlled trial. First sixty randomized patients. Journal of Interventional Cardiac Electrophysiology. 2012;33(3):333.
Liew D, Lee J, Gonzalo F. Dronedarone is cost-effective for the prevention of downstream cardiovascular morbidity and mortality in Australian patients with atrial fibrillation. Value Health. 2011;14(7):A381.
Lim T, Koay C, See V, et al. Single ring posterior left atrial isolation results in fewer recurrent atrial arrhythmias than wide antral isolation after two or more procedures. Heart Lung and Circulation. 2011;20:S109.
Lim T, Koay C, See V, et al. Single ring posterior left atrial (box) isolation results in fewer AF recurrences than wide antral pulmonary vein isolation on long term follow up. Heart Lung and Circulation. 2011;20:S108.
Lovell MJ, Duncan ER, Baker V, et al. Cryoballoon ablation is superior to RF ablation in preventing recurrence of. Heart Rhythm. 2012;9(5 SUPPL. 1):S492.
Marzouka GR, Rathod A, Patel N, et al. Rate control is superior to rhythm control in patients with atrial fibrillation and a pacemaker. Heart Rhythm. 2012;9(5 SUPPL. 1):S317-S318.
Matsuo S, Yamane T, Miyamoto M, et al. The randomized comparison of clinical outcomes of supplemental atrial ablations in patients with persistent atrial fibrillation. Heart Rhythm. 2012;9(5 SUPPL. 1):S318.
Moghaddam M, Bagher Zadeh A, Moshkani Farahani M. Effects of atrioventricular node ablation in patients with chronicatrial fibrillation candidate for cardiac resynchronization therapy. PACE - Pacing and Clinical Electrophysiology. 2011;34(11):1379-1380.
Mokrani BO, Sarrazin JF, Champagne J, et al. Prospective study comparing duty-cycled bipolar and unipolar radiofrequency to pulmonary vein isolation by point-by-point ablation and cryoballoon ablation. Heart Rhythm. 2012;9(5 SUPPL. 1):S416.
Nielsen JC. A randomized multicentre comparison of radiofrequency ablation and anti-arrhythmic drug therapy as first-line treatment in 294 patients with paroxysmal atrial fibrillation. European Heart Journal. 2012;33(1):142-143.
Nieuwlaat R, Hohnloser SH, Connolly SJ. Effect of dronedarone in patients with permanent atrial fibrillation during the ATHENA study. Eur Heart J. 2011;32:618. [pmid: 20846993].
Oliva F, Gasparini M, Proclemer A, et al. Incidence and clinical relevance of uncontrolled ventricular rate during atrial fibrillation in heart failure patients treated with cardiac resynchronization therapy. Eur J Heart Fail. Supplement. 2011;10:S7.
Podd S, Sulke N, Veasey R, et al. Left atrial ablation combined with AV node ablation is superior to AV node ablation alone in long-standing persistent atrial fibrillation patients-a prospective single-blind randomised trial. Journal of Interventional Cardiac Electrophysiology. 2012;33(3):346.
Pokushalov E, Romanov A, Artemenko S, et al. Two different ablation strategies in patients with paroxysmal atrial fibrillation: A randomized comparison. Eur Heart J. 2011;32:799. [pmid: 21398645].
Pokushalov E, Romanov A, Artemenko S, et al. Two different ablation strategies in patients with paroxysmal atrial fibrillation: A prospective randomized comparison. Europace. 2011;13(3):2011-06.
Rebecchi M, De Ruvo E, Sciarra L, et al. Ablation of long-lasting persistent atrial fibrillation by intraprocedural using of ibutilide to identify persistent cfaes: Results from a randomized study comparing two different strategies. PACE - Pacing and Clinical Electrophysiology. 2011;34(11):1368.
Rebecchi M, Sciarra L, De Ruvo E, et al. Ablation of long-lasting persistent atrial fibrillation by intraprocedural use of ibutilide to identify persistent CFAEs. Results from a randomized study comparing two different strategies. Giornale Italiano di Cardiologia. 2011;12(5 SUPPL. 1):54S.
Rho RW, Page RL. Biphasic versus monophasic shock waveform for conversion of atrial fibrillation. Card Electrophysiol Rev. 2003;7(3):290-1. [pmid: 14739730].
Romanov A, Pokushalov E, Shabanov V, et al. Two different ablation strategies in patients with paroxysmal atrial fibrillation: A prospective randomized comparison. PACE - Pacing and Clinical Electrophysiology. 2011;34(11):1314.
Roumie CL. Atrial fibrillation: Primary treatment with medication versus ablation. J Clin Outcomes Manag. 2005;12(7):342-343.
Singh SN, Singh BN, Reda DJ, et al. Comparison of sotalol versus amiodarone in maintaining stability of sinus rhythm in patients with atrial fibrillation (Sotalol-Amiodarone Fibrillation Efficacy Trial [Safe-T]). Am J Cardiol. 2003;92(4):468-72. [pmid: 12914883].
Suzuki T, Yamazaki T, Ogawa S, et al. Echocardiographic predictors of progression from paroxysmal to persistent atrial fibrillation: Result from the Japanese rhythm management trial II for atrial fibrillation (J-rhythm II) study. Circulation. 2011;124(21):2011-11.
Thibault B, Ducharme A, Simpson C, et al. SafeR pacing mode consistently prevents ventricular pacing over a 2-year follow-up. Europace. 2011;13(3):2011-06.
Tomasi L, Lunati M, Gasparini M, et al. Incidence and clinical relevance of uncontrolled ventricular rate during atrial fibrillation in heart failure patients treated with cardiac resynchronization therapy. J Cardiovasc Electrophysiol. 2011;22:S8-S9.
Van Gelder IC, Hagens V, Bosker H, et al. Ventricular rate control may be an alternative to sinus rhythm control in persistent atrial fibrillation. Evidence-based Cardiovascular Medicine. 2003;7(2):92-93.
Vardas PE, Kochiadakis GE. Amiodarone for the restoration of sinus rhythm in patients with atrial fibrillation. Card Electrophysiol Rev. 2003;7(3):297-9. [pmid: 14739732].
Wong KCK, Paisey J, Qureshi N, et al. Ablation of complex fractionated atrial electrogram (CFAE) in addition to pulmonary vein isolation and linear ablation does not improve single procedural success rate of catheter ablation for persistent atrial fibrillation. Heart Rhythm. 2012;9(5 SUPPL. 1):S271-S272.
Yamashiro K, Takami K, Sakamoto Y, et al. Efficacy of ganglionated plexi ablation plus pulmonary vein isolation for atrial fibrillation. Europace. 2011;13(3):2011-06.

## Not an RCT of ≥20 Patients or an Observational Study of ≥100 Patients

Alcaraz R, Hornero F, Rieta JJ. Enhancement of atrial fibrillation electrical cardioversion procedures through the arrhythmia organization estimation from the ECG. Conf Proc IEEE Eng Med Biol Soc. 2010. 2010:122-5. [pmid: 21096522].
Anselme F, Savoure A, Cribier A, et al. Catheter ablation of typical atrial flutter: a randomized comparison of 2 methods for determining complete bidirectional isthmus block. Circulation. 2001;103(10):1434-9. [pmid: 11245649].
Ariansen I, Abdelnoor M, Tveit A, et al. Guidelines' criteria for rate control in atrial fibrillation: are they useful?. Scand Cardiovasc J. 2010;44(3):132-8. [pmid: 20184511].
Bollmann A, Binias KH, Toepffer I, et al. Importance of left atrial diameter and atrial fibrillatory frequency for conversion of persistent atrial fibrillation with oral flecainide. Am J Cardiol. 2002;90(9):1011-4. [pmid: 12398975].
Brignole M, Botto GL, Mont L, et al. Predictors of clinical efficacy of ‘Ablate and Pace’ therapy in patients with permanent atrial fibrillation. Heart. 2012;98(4):297-302. [pmid: 22095616].
Candeias R, Adragcao P, Cavaco D, et al. Atrial fibrillation ablation: importance of cavotricuspid isthmus block. Rev Port Cardiol. 2009;28(10):1031-40. [pmid: 20058772].
Cauchemez B, Extramiana F, Cauchemez S, et al. High-flow perfusion of sheaths for prevention of thromboembolic complications during complex catheter ablation in the left atrium. J Cardiovasc Electrophysiol. 2004;15(3):276-83. [pmid: 15030415].
Chae S, Oral H, Good E, et al. Atrial tachycardia after circumferential pulmonary vein ablation of atrial fibrillation: mechanistic insights, results of catheter ablation, and risk factors for recurrence. J Am Coll Cardiol. 2007;50(18):1781-7. [pmid: 17964043].
Chaiyaroj S, Ngarmukos T, Lertsithichai P. Predictors of sinus rhythm after radiofrequency maze and mitral valve surgery. Asian Cardiovasc Thorac Ann. 2008;16(4):292-7. [pmid: 18670021].
Chang JP, Chen MC, Kao CL, et al. Role of the simultaneous sequential strategy for failed acute sinus restoration after modified left maze procedure for persistent atrial fibrillation with concomitant mitral surgery. World J Surg. 2006;30(10):1802-8. [pmid: 16983460].
Chang SL, Tai CT, Lin YJ, et al. The efficacy of inducibility and circumferential ablation with pulmonary vein isolation in patients with paroxysmal atrial fibrillation. J Cardiovasc Electrophysiol. 2007;18(6):607-11. [pmid: 17488268].
Cheema A, Dong J, Dalal D, et al. Long-term safety and efficacy of circumferential ablation with pulmonary vein isolation. J Cardiovasc Electrophysiol. 2006;17(10):1080-5. [pmid: 16989649].
Chen J, Hoff PI, Erga KS, et al. A clinical study of patients with and without recurrence of paroxysmal atrial fibrillation after pulmonary vein isolation. Pacing Clin Electrophysiol. Suppl 1. 2005;28:S86-9. [pmid: 15683535].
Chen J, Off MK, Solheim E, et al. Treatment of atrial fibrillation by silencing electrical activity in the posterior inter-pulmonary-vein atrium. Europace. 2008;10(3):265-72. [pmid: 18308750].
Chen MC, Chang JP, Chang HW, et al. Clinical determinants of sinus conversion by radiofrequency maze procedure for persistent atrial fibrillation in patients undergoing concomitant mitral valvular surgery. Am J Cardiol. 2005;96(11):1553-7. [pmid: 16310439].
Chen MC, Chang JP, Chen CJ, et al. Atrial pacemaker complex preserved radiofrequency maze procedure reducing the incidence of sick sinus syndrome in patients with atrial fibrillation. Chest. 2005;128(4):2571-5. [pmid: 16236925].
Chiladakis J, Koutsogiannis N, Kalogeropoulos A, et al. Usefulness of rate regulation through continuous ventricular pacing in patients with drug-controlled slower atrial fibrillation and normal or depressed left ventricular systolic function. Heart Vessels. 2008;23(6):403-8. [pmid: 19037588].
Chiladakis JA, Koutsogiannis N, Kalogeropoulos A, et al. Adverse effects of continuous ventricular pacing in patients with slower atrial fibrillation and normal left ventricular systolic function. Ann Noninvasive Electrocardiol. 2008;13(2):130-6. [pmid: 18426438].
Chilukuri K, Dukes J, Dalal D, et al. Outcomes in patients requiring cardioversion following catheter ablation of atrial fibrillation. J Cardiovasc Electrophysiol. 2010;21(1):27-32. [pmid: 19793148].
Choi JI, Pak HN, Park JH, et al. Clinical significance of complete conduction block of the left lateral isthmus and its relationship with anatomical variation of the vein of Marshall in patients with nonparoxysmal atrial fibrillation. J Cardiovasc Electrophysiol. 2009;20(6):616-22. [pmid: 19207770].
Christiansen S, Klocke A, Schmid M, et al. Short and midterm results of epi and endocardial cryoablation. Ann Thorac Cardiovasc Surg. 2010;16(5):340-4. [pmid: 21030921].
Chugh A, Oral H, Good E, et al. Catheter ablation of atypical atrial flutter and atrial tachycardia within the coronary sinus after left atrial ablation for atrial fibrillation. J Am Coll Cardiol. 2005;46(1):83-91. [pmid: 15992640].
Chun KR, Furnkranz A, Koster I, et al. Two Versus One Repeat Freeze-Thaw Cycle(s) After Cryoballoon Pulmonary Vein Isolation: The ALSTER EXTRA Pilot Study. J Cardiovasc Electrophysiol. 2012. [pmid: 22487260].
Conway DS, Buggins P, Hughes E, et al. Predictive value of indexes of inflammation and hypercoagulability on success of cardioversion of persistent atrial fibrillation. Am J Cardiol. 2004;94(4):508-10. [pmid: 15325942].
Coro L, Delise P, Bertaglia E, et al. The duration of atrial fibrillation influences the long-term efficacy of low-energy internal cardioversion. Ital Heart J. 2001;2(5):388-93. [pmid: 11392645].
Cosgrave J, Foley JB, Bahadur K, et al. Inflammatory markers are not associated with outcomes following elective external cardioversion. Int J Cardiol. 2006;110(3):373-7. [pmid: 16257462].
Crawford TC, Wimmer A, Dey S, et al. Mechanism of recurrence after radiofrequency catheter ablation of atrial fibrillation guided by complex fractionated atrial electrograms. J Interv Card Electrophysiol. 2008;21(1):27-33. [pmid: 18044014].
Cui YQ, Li Y, Gao F, et al. Video-assisted minimally invasive surgery for lone atrial fibrillation: a clinical report of 81 cases. J Thorac Cardiovasc Surg. 2010;139(2):326-32. [pmid: 19660413].
Cui YQ, Sun LB, Li Y, et al. Intraoperative modified Cox mini-maze procedure for long-standing persistent atrial fibrillation. Ann Thorac Surg. 2008;85(4):1283-9. [pmid: 18355511].
Degener S, Pattberg SV, Feuersenger H, et al. Predictive value of B-type natriuretic peptide levels in patients with paroxysmal and persistent atrial fibrillation undergoing pulmonary vein isolation. J Interv Card Electrophysiol. 2011;30(3):217-25. [pmid: 21249437].
Deisenhofer I, Estner H, Zrenner B, et al. Left atrial tachycardia after circumferential pulmonary vein ablation for atrial fibrillation: incidence, electrophysiological characteristics, and results of radiofrequency ablation. Europace. 2006;8(8):573-82. [pmid: 16864612].
Delle Karth G, Schillinger M, Geppert A, et al. Ibutilide for rapid conversion of atrial fibrillation or flutter in a mixed critically ill patient population. Wien Klin Wochenschr. 2005;117(3):92-7. [pmid: 15773423].
Demirkilic U, Bolcal C, Gunay C, et al. Results of endocardial radiofrequency ablation of atrial fibrillation during mitral valve surgery. J Cardiovasc Surg (Torino). 2006;47(4):469-75. [pmid: 16953168].
den Uijl DW, Delgado V, Tops LF, et al. Natriuretic peptide levels predict recurrence of atrial fibrillation after radiofrequency catheter ablation. Am Heart J. 2011;161(1):197-203. [pmid: 21167354].
den Uijl DW, Tops LF, Delgado V, et al. Effect of pulmonary vein anatomy and left atrial dimensions on outcome of circumferential radiofrequency catheter ablation for atrial fibrillation. Am J Cardiol. 2011;107(2):243-9. [pmid: 21211601].
Efremidis M, Sideris A, Batra R, et al. Facilitating internal cardioversion of chronic atrial fibrillation with ibutilide--predictors of atrial defibrillation-threshold decrease. Med Sci Monit. 2004;10(6):CR258-63. [pmid: 15173670].
Filipecki A, Saksena S, Lin WH. Effectiveness of rhythm control in persistent or permanent atrial fibrillation with overdrive atrial pacing and antiarrhythmic drugs after linear right atrial catheter ablation. Am J Cardiol. 2003;92(9):1037-44. [pmid: 14583353].
Forlani S, De Paulis R, Guerrieri Wolf L, et al. Conversion to sinus rhythm by ablation improves quality of life in patients submitted to mitral valve surgery. Ann Thorac Surg. 2006;81(3):863-7. [pmid: 16488685].
Goktekin O, Melek M, Timuralp B, et al. Internal cardioversion of atrial fibrillation under transesophageal echocardiography guidance without fluoroscopy using single-lead catheter technique. Am J Cardiol. 2002;90(3):328-31. [pmid: 12127625].
Himmel F, Reppel M, Mortensen K, et al. A strategy to achieve CRT response in permanent atrial fibrillation without obligatory atrioventricular node ablation. Pacing Clin Electrophysiol. 2012. [pmid: 22650352].
Kaluski E, Blatt A, Leitman M, et al. Atropine-facilitated electrical cardioversion of persistent atrial fibrillation. Am J Cardiol. 2003;92(9):1119-22. [pmid: 14583370].
Kress DC, Sra J, Krum D, et al. Radiofrequency ablation of atrial fibrillation during mitral valve surgery. Semin Thorac Cardiovasc Surg. 2002;14(3):210-8. [pmid: 12232860].
Krittayaphong R, Chotinaiwatarakul C, Phankingthongkum R, et al. One-year outcome of cardioversion of atrial fibrillation in patients with mitral stenosis after percutaneous balloon mitral valvuloplasty. Am J Cardiol. 2006;97(7):1045-50. [pmid: 16563913].
Kubota S, Sugiki H, Wakasa S, et al. Can we change the operative criteria for the MAZE procedure combined with valve surgery in the era of radiofrequency devices?. Gen Thorac Cardiovasc Surg. 2011;59(6):406-12. [pmid: 21674307].
Kuhne M, Suter Y, Altmann D, et al. Cryoballoon versus radiofrequency catheter ablation of paroxysmal atrial fibrillation: biomarkers of myocardial injury, recurrence rates, and pulmonary vein reconnection patterns. Heart Rhythm. 2010;7(12):1770-6. [pmid: 20817019].
Kumagai K, Gondo N, Matsumoto N, et al. New technique for simultaneous catheter mapping of pulmonary veins for catheter ablation in focal atrial fibrillation. Cardiology. 2000;94(4):233-8. [pmid: 11326144].
Kumagai K, Noguchi H, Ogawa M, et al. New approach to pulmonary vein isolation for atrial fibrillation using a multielectrode basket catheter. Circ J. 2006;70(1):88-93. [pmid: 16377930].
Lazar S, Dixit S, Callans DJ, et al. Effect of pulmonary vein isolation on the left-to-right atrial dominant frequency gradient in human atrial fibrillation. Heart Rhythm. 2006;3(8):889-95. [pmid: 16876735].
Lin JL, Lai LP, Tseng YZ, et al. Global distribution of atrial ectopic foci triggering recurrence of atrial tachyarrhythmia after electrical cardioversion of long-standing atrial fibrillation: a bi-atrial basket mapping study. J Am Coll Cardiol. 2001;37(3):904-10. [pmid: 11693769].
Narayan SM, Krummen DE, Shivkumar K, et al. Treatment of atrial fibrillation by the ablation of localized sources: CONFIRM (Conventional Ablation for Atrial Fibrillation With or Without Focal Impulse and Rotor Modulation) Trial. J Am Coll Cardiol. 2012. [pmid: 22818076].
Rienstra M, Van Gelder IC, Van den Berg MP, et al. A comparison of low versus high heart rate in patients with atrial fibrillation and advanced chronic heart failure: effects on clinical profile, neurohormones and survival. Int J Cardiol. 2006;109(1):95-100. [pmid: 15993501].
Sharp JC, Whalley DW. Effectiveness and safety of low-energy internal cardioversion of long-standing atrial fibrillation after unsuccessful external cardioversion. Am J Cardiol. 2002;90(6):657-60. [pmid: 12231100].
Sticherling C, Behrens S, Kamke W, et al. Comparison of acute and long-term effects of single-dose amiodarone and verapamil for the treatment of immediate recurrences of atrial fibrillation after transthoracic cardioversion. Europace. 2005;7(6):546-53. [pmid: 16216756].
Sticherling C, Ozaydin M, Tada H, et al. Comparison of verapamil and ibutilide for the suppression of immediate recurrences of atrial fibrillation after transthoracic cardioversion. J Cardiovasc Pharmacol Ther. 2002;7(3):155-60. [pmid: 12232564].
Suwalski P, Suwalski G, Kurowski A, et al. Use of new liquid nitrogen cryocatheter in the surgical treatment of atrial fibrillation: clinical experience, mid- and long-term results. Comput Biol Med. 2007;37(10):1409-13. [pmid: 17316597].
Tolosana JM, Arnau AM, Madrid AH, et al. Cardiac resynchronization therapy in patients with permanent atrial fibrillation. Is it mandatory to ablate the atrioventricular junction to obtain a good response?. Eur J Heart Fail. 2012;14(6):635-41. [pmid: 22396459].
Tse HF, Lau CP, Wang Q, et al. Effect of diltiazem on the recurrence rate of paroxysmal atrial fibrillation. Am J Cardiol. 2001;88(5):568-70. [pmid: 11524073].
Wang HE, O'Connor R E, Megargel RE, et al. The use of diltiazem for treating rapid atrial fibrillation in the out-of-hospital setting. Ann Emerg Med. 2001;37(1):38-45. [pmid: 11145769].

## Not a Study Population of Interest

Acikel S, Bozbas H, Gultekin B, et al. Comparison of the efficacy of metoprolol and carvedilol for preventing atrial fibrillation after coronary bypass surgery. Int J Cardiol. 2008;126(1):108-13. [pmid: 17499863].
Akbarzadeh F, Kazemi-Arbat B, Golmohammadi A, et al. Biatrial pacing vs. intravenous amiodarone in prevention of atrial fibrillation after coronary artery bypass surgery. Pak J Biol Sci. 2009;12(19):1325-9. [pmid: 20387748].
Alcalde RV, Guaragna JC, Bodanese LC, et al. High dose of amiodarone in a short-term period reduces the incidence of postoperative atrial fibrillation and atrial flutter. Arq Bras Cardiol. 2006;87(3):236-40. [pmid: 17057920].
Alex J, Guvendik L. Evaluation of ventral cardiac denervation as a prophylaxis against atrial fibrillation after coronary artery bypass grafting. Ann Thorac Surg. 2005;79(2):517-20. [pmid: 15680826].
Alves RJ, Geovanini GR, Brito G, et al. Prevention of atrial fibrillation with moderate doses of amiodarone in the postoperative period of cardiac surgery is safe and effective in patients with high risk for developing this arrhythmia. Arq Bras Cardiol. 2007;89(1):22-7. [pmid: 17768579].
Amar D, Roistacher N, Rusch VW, et al. Effects of diltiazem prophylaxis on the incidence and clinical outcome of atrial arrhythmias after thoracic surgery. J Thorac Cardiovasc Surg. 2000;120(4):790-8. [pmid: 11003764].
Anselme F, Klug D, Scanu P, et al. Randomized comparison of two targets in typical atrial flutter ablation. Am J Cardiol. 2000;85(11):1302-7. [pmid: 10831944].
Auer J, Weber T, Berent R, et al. A comparison between oral antiarrhythmic drugs in the prevention of atrial fibrillation after cardiac surgery: the pilot study of prevention of postoperative atrial fibrillation (SPPAF), a randomized, placebo-controlled trial. Am Heart J. 2004;147(4):636-43. [pmid: 15077078].
Bai R, Biase LD, Mohanty P, et al. Ablation of Perimitral Flutter Following Catheter Ablation of Atrial Fibrillation: Impact on Outcomes from a Randomized Study (PROPOSE). J Cardiovasc Electrophysiol. 2012;23(2):137-44. [pmid: 21955215].
Bai R, Fahmy TS, Patel D, et al. Radiofrequency ablation of atypical atrial flutter after cardiac surgery or atrial fibrillation ablation: a randomized comparison of open-irrigation-tip and 8-mm-tip catheters. Heart Rhythm. 2007;4(12):1489-96. [pmid: 17997363].
Balcetyte-Harris N, Tamis JE, Homel P, et al. Randomized study of early intravenous esmolol versus oral beta-blockers in preventing post-CABG atrial fibrillation in high risk patients identified by signal-averaged ECG: results of a pilot study. Ann Noninvasive Electrocardiol. 2002;7(2):86-91. [pmid: 12049678].
Bernard EO, Schmid ER, Schmidlin D, et al. Ibutilide versus amiodarone in atrial fibrillation: a double-blinded, randomized study. Crit Care Med. 2003;31(4):1031-4. [pmid: 12682468].
Buck S, Rienstra M, Maass AH, et al. Cardiac resynchronization therapy in patients with heart failure and atrial fibrillation: importance of new-onset atrial fibrillation and total atrial conduction time. Europace. 2008;10(5):558-65. [pmid: 18356205].
Calo L, Rebecchi M, Sciarra L, et al. Catheter ablation of right atrial ganglionated plexi in patients with vagal paroxysmal atrial fibrillation. Circ Arrhythm Electrophysiol. 2012;5(1):22-31. [pmid: 22147839].
Deneke T, Khargi K, Grewe PH, et al. Catheter ablation of regular atrial arrhythmia following surgical treatment of permanent atrial fibrillation. J Cardiovasc Electrophysiol. 2006;17(1):18-24. [pmid: 16426394].
Gulizia M, Mangiameli S, Orazi S, et al. A randomized comparison of amiodarone and class IC antiarrhythmic drugs to treat atrial fibrillation in patients paced for sinus node disease: the Prevention Investigation and Treatment: A Group for Observation and Research on Atrial arrhythmias (PITAGORA) trial. Am Heart J. 2008;155(1):100-7. 107 e1. [pmid: 18082498].
Hoppe UC, Casares JM, Eiskjaer H, et al. Effect of cardiac resynchronization on the incidence of atrial fibrillation in patients with severe heart failure. Circulation. 2006;114(1):18-25. [pmid: 16801461].
Oral H, Ozaydin M, Tada H, et al. Comparison of amiodarone versus ibutilide for the prevention of immediate recurrences of atrial fibrillation during pulmonary vein isolation. Am J Cardiol. 2002;90(5):492-5. [pmid: 12208408].
Pinter A, Dorian P, Paquette M, et al. Left ventricular performance during acute rate control in atrial fibrillation: the importance of heart rate and agent used. J Cardiovasc Pharmacol Ther. 2003;8(1):17-24. [pmid: 12652326].
Sakamoto A, Kitakaze M, Takamoto S, et al. Landiolol, an ultra-short-acting beta(1)-blocker, more effectively terminates atrial fibrillation than diltiazem after open heart surgery: prospective, multicenter, randomized, open-label study (JL-KNIGHT study). Circ J. 2012;76(5):1097-101. [pmid: 22361918].
Schneider MA, Ndrepepa G, Dobran I, et al. LocaLisa catheter navigation reduces fluoroscopy time and dosage in ablation of atrial flutter: a prospective randomized study. J Cardiovasc Electrophysiol. 2003;14(6):587-90. [pmid: 12875418].

## No Intervention/Comparator of Interest

Ahmed S, Ranchor AV, Crijns HJ, et al. Effect of continuous versus episodic amiodarone treatment on quality of life in persistent atrial fibrillation. Europace. 2010;12(6):785-91. [pmid: 20200016].
Ahmed S, Rienstra M, Crijns HJ, et al. Continuous vs episodic prophylactic treatment with amiodarone for the prevention of atrial fibrillation: a randomized trial. JAMA. 2008;300(15):1784-92. [pmid: 18854540].
Aizawa Y, Kohsaka S, Suzuki S, et al. Comparison of antiarrhythmics used in patients with paroxysmal atrial fibrillation: subanalysis of J-RHYTHM Study. Circ J. 2010;74(1):71-6. [pmid: 19955694].
Almroth H, Hoglund N, Boman K, et al. Atorvastatin and persistent atrial fibrillation following cardioversion: a randomized placebo-controlled multicentre study. Eur Heart J. 2009;30(7):827-33. [pmid: 19202157].
Alp NJ, Bell JA, Shahi M. Randomised double blind trial of oral versus intravenous flecainide for the cardioversion of acute atrial fibrillation. Heart. 2000;84(1):37-40. [pmid: 10862585].
Ardestani A, Hoffman HJ, Cooper HA. Obesity and outcomes among patients with established atrial fibrillation. Am J Cardiol. 2010;106(3):369-73. [pmid: 20643247].
Atarashi H, Inoue H, Fukunami M, et al. Double-blind placebo-controlled trial of aprindine and digoxin for the prevention of symptomatic atrial fibrillation. Circ J. 2002;66(6):553-6. [pmid: 12074271].
Atarashi H, Ogawa S, Inoue H, et al. Dose-response effect of flecainide in patients with symptomatic paroxysmal atrial fibrillation and/or flutter monitored with trans-telephonic electrocardiography: a multicenter, placebo-controlled, double-blind trial. Circ J. 2007;71(3):294-300. [pmid: 17322624].
Bailin SJ, Adler S, Giudici M. Prevention of chronic atrial fibrillation by pacing in the region of Bachmann's bundle: results of a multicenter randomized trial. J Cardiovasc Electrophysiol. 2001;12(8):912-7. [pmid: 11513442].
Bellone A, Etteri M, Vettorello M, et al. Cardioversion of acute atrial fibrillation in the emergency department: a prospective randomised trial. Emerg Med J. 2011;29(3):188-91. [pmid: 21422032].
Bianconi L, Calo L, Mennuni M, et al. n-3 polyunsaturated fatty acids for the prevention of arrhythmia recurrence after electrical cardioversion of chronic persistent atrial fibrillation: a randomized, double-blind, multicentre study. Europace. 2011;13(2):174-81. [pmid: 21059740].
Bianconi L, Castro A, Dinelli M, et al. Comparison of intravenously administered dofetilide versus amiodarone in the acute termination of atrial fibrillation and flutter. A multicentre, randomized, double-blind, placebo-controlled study. Eur Heart J. 2000;21(15):1265-73. [pmid: 10924317].
Boriani G, Biffi M, Camanini C, et al. Transvenous internal cardioversion for atrial fibrillation: a randomized comparison between catheters with different coil length. Am Heart J. 2002;144(5):851-7. [pmid: 12422155].
Boriani G, Gasparini M, Landolina M, et al. Incidence and clinical relevance of uncontrolled ventricular rate during atrial fibrillation in heart failure patients treated with cardiac resynchronization therapy. Eur J Heart Fail. 2011;13(8):868-876. [pmid: 21558331].
Brignole M, Gammage M, Puggioni E, et al. Comparative assessment of right, left, and biventricular pacing in patients with permanent atrial fibrillation. Eur Heart J. 2005;26(7):712-22. [pmid: 15618036].
Calo L, Rebecchi M, Sciarra L, et al. Catheter Ablation of Right Atrial Ganglionated Plexi in Patients with Vagal Paroxysmal Atrial Fibrillation. Circ Arrhythm Electrophysiol. 2012;5(1):22-31. [pmid: 22147839].
Camm AJ, Capucci A, Hohnloser SH, et al. A randomized active-controlled study comparing the efficacy and safety of vernakalant to amiodarone in recent-onset atrial fibrillation. J Am Coll Cardiol. 2011;57(3):313-21. [pmid: 21232669].
Camm AJ, Sulke N, Edvardsson N, et al. Conventional and dedicated atrial overdrive pacing for the prevention of paroxysmal atrial fibrillation: the AFTherapy study. Europace. 2007;9(12):1110-8. [pmid: 18042619].
Caponi D, Corleto A, Scaglione M, et al. Ablation of atrial fibrillation: does the addition of three-dimensional magnetic resonance imaging of the left atrium to electroanatomic mapping improve the clinical outcome?: a randomized comparison of Carto-Merge vs. Carto-XP three-dimensional mapping ablation in patients with paroxysmal and persistent atrial fibrillation. Europace. 2010;12(8):1098-104. [pmid: 20400766].
Capucci A, Botto G, Molon G, et al. The Drug And Pace Health cliNical Evaluation (DAPHNE) study: a randomized trial comparing sotalol versus beta-blockers to treat symptomatic atrial fibrillation in patients with brady-tachycardia syndrome implanted with an antitachycardia pacemaker. Am Heart J. 2008;156(2):373 e1-8. [pmid: 18657671].
Carlson MD, Ip J, Messenger J, et al. A new pacemaker algorithm for the treatment of atrial fibrillation: results of the Atrial Dynamic Overdrive Pacing Trial (ADOPT). J Am Coll Cardiol. 2003;42(4):627-33. [pmid: 12932592].
Channer KS, Birchall A, Steeds RP, et al. A randomized placebo-controlled trial of pre-treatment and short- or long-term maintenance therapy with amiodarone supporting DC cardioversion for persistent atrial fibrillation. Eur Heart J. 2004;25(2):144-50. [pmid: 14720531].
Chiladakis JA, Stathopoulos C, Davlouros P, et al. Intravenous magnesium sulfate versus diltiazem in paroxysmal atrial fibrillation. Int J Cardiol. 2001;79(2-3):287-91. [pmid: 11461753].
Chu K, Evans R, Emerson G, et al. Magnesium sulfate versus placebo for paroxysmal atrial fibrillation: a randomized clinical trial. Acad Emerg Med. 2009;16(4):295-300. [pmid: 19207134].
Climent VE, Marin F, Mainar L, et al. Effects of pretreatment with intravenous flecainide on efficacy of external cardioversion of persistent atrial fibrillation. Pacing Clin Electrophysiol. 2004;27(3):368-72. [pmid: 15009866].
Connolly SJ, Camm AJ, Halperin JL, et al. Dronedarone in High-Risk Permanent Atrial Fibrillation. N Engl J Med. 2011;365(24):2268-76. [pmid: 22082198].
Connolly SJ, Crijns HJ, Torp-Pedersen C, et al. Analysis of stroke in ATHENA: a placebo-controlled, double-blind, parallel-arm trial to assess the efficacy of dronedarone 400 mg BID for the prevention of cardiovascular hospitalization or death from any cause in patients with atrial fibrillation/atrial flutter. Circulation. 2009;120(13):1174-80. [pmid: 19752319].
Cybulski J, Kulakowski P, Budaj A, et al. Intravenous amiodarone for cardioversion of recent-onset atrial fibrillation. Clin Cardiol. 2003;26(7):329-35. [pmid: 12862299].
Da Costa A, Thevenin J, Roche F, et al. Results from the Loire-Ardeche-Drome-Isere-Puy-de-Dome (LADIP) trial on atrial flutter, a multicentric prospective randomized study comparing amiodarone and radiofrequency ablation after the first episode of symptomatic atrial flutter. Circulation. 2006;114(16):1676-81. [pmid: 17030680].
Davey MJ, Teubner D. A randomized controlled trial of magnesium sulfate, in addition to usual care, for rate control in atrial fibrillation. Ann Emerg Med. 2005;45(4):347-53. [pmid: 15795711].
Davy JM, Herold M, Hoglund C, et al. Dronedarone for the control of ventricular rate in permanent atrial fibrillation: the Efficacy and safety of dRonedArone for the cOntrol of ventricular rate during atrial fibrillation (ERATO) study. Am Heart J. 2008;156(3):527 e1-9. [pmid: 18760136].
de Paola AA, Figueiredo E, Sesso R, et al. Effectiveness and costs of chemical versus electrical cardioversion of atrial fibrillation. Int J Cardiol. 2003;88(2-3):157-66. [pmid: 12714194].
de Voogt W, van Hemel N, de Vusser P, et al. No evidence of automatic atrial overdrive pacing efficacy on reduction of paroxysmal atrial fibrillation. Europace. 2007;9(9):798-804. [pmid: 17670782].
Deakin CD, Connelly S, Wharton R, et al. A comparison of rectilinear and truncated exponential biphasic waveforms in elective cardioversion of atrial fibrillation: a prospective randomized controlled trial. Resuscitation. 2012. [pmid: 22842285].
Della Bella P, Fassini G, Cireddu M, et al. Image integration-guided catheter ablation of atrial fibrillation: a prospective randomized study. J Cardiovasc Electrophysiol. 2009;20(3):258-65. [pmid: 19261038].
den Uijl DW, Gawrysiak M, Tops LF, et al. Prognostic value of total atrial conduction time estimated with tissue Doppler imaging to predict the recurrence of atrial fibrillation after radiofrequency catheter ablation. Europace. 2011;13(11):1533-40. [pmid: 21712264].
Deng M, Sui XQ, Zhu SB, et al. Clinical observation on the treatment of atrial fibrillation with amiodarone combined with Shenmai Injection (). Chin J Integr Med. 2010;16(5):453-6. [pmid: 20872121].
Di Biase L, Conti S, Mohanty P, et al. General anesthesia reduces the prevalence of pulmonary vein reconnection during repeat ablation when compared with conscious sedation: results from a randomized study. Heart Rhythm. 2011;8(3):368-72. [pmid: 21055479].
Di Biase L, Saenz LC, Burkhardt DJ, et al. Esophageal capsule endoscopy after radiofrequency catheter ablation for atrial fibrillation: documented higher risk of luminal esophageal damage with general anesthesia as compared with conscious sedation. Circ Arrhythm Electrophysiol. 2009;2(2):108-12. [pmid: 19808454].
Di Biase L, Santangelli P, Mohanty P, et al. Amiodarone increases the AF termination during ablation but reduces the long term success rate of patients undergoing ablation of long-standing persistent atrial fibrillation: Preliminary results from the speculate study. Heart Rhythm. 2012;9(5 SUPPL. 1):S37.
Dogan A, Ergene O, Nazli C, et al. Efficacy of propafenone for maintaining sinus rhythm in patients with recent onset or persistent atrial fibrillation after conversion: a randomized, placebo-controlled study. Acta Cardiol. 2004;59(3):255-61. [pmid: 15255456].
Doni F, Manfredi M, Piemonti C, et al. New onset atrial flutter termination by overdrive transoesophageal pacing: effects of different protocols of stimulation. Europace. 2000;2(4):292-6. [pmid: 11194595].
Duff HJ, Raj SR, Exner DV, et al. Randomized controlled trial of fixed rate versus rate responsive pacing after radiofrequency atrioventricular junction ablation: quality of life, ventricular refractoriness, and paced QT dispersion. J Cardiovasc Electrophysiol. 2003;14(11):1163-70. [pmid: 14678128].
Estner HL, Deisenhofer I, Luik A, et al. Electrical isolation of pulmonary veins in patients with atrial fibrillation: reduction of fluoroscopy exposure and procedure duration by the use of a non-fluoroscopic navigation system (NavX). Europace. 2006;8(8):583-7. [pmid: 16831837].
Ezekowitz MD, Nagarakanti R, Lubinski A, et al. A randomized trial of budiodarone in paroxysmal atrial fibrillation. J Interv Card Electrophysiol. 2012;34(1):1-9. [pmid: 22205496].
Finlay MC, Hunter RJ, Baker V, et al. A randomised comparison of Cartomerge vs. NavX fusion in the catheter ablation of atrial fibrillation: The CAVERN Trial. J Interv Card Electrophysiol. 2012;33(2):161-9. [pmid: 22119854].
Fogari R, Mugellini A, Derosa G, et al. Effect of telmisartan on paroxymal atrial fibrillation in hypertensive patients with different left atrial size. Circulation. 2011;124(21):2011-11.
Fragakis N, Koskinas KC, Katritsis DG, et al. Comparison of Effectiveness of Ranolazine Plus Amiodarone Versus Amiodarone Alone for Conversion of Recent-Onset Atrial Fibrillation. Am J Cardiol. 2012. [pmid: 22621799].
Frasure-Smith N, Lesperance F, Talajic M, et al. Anxiety sensitivity moderates prognostic importance of rhythm-control versus rate-control strategies in patients with atrial fibrillation and congestive heart failure: insights from. the Atrial Fibrillation and Congestive Heart Failure Trial Circ Heart Fail. 2012;5(3):322-30. [pmid: 22441774].
Friberg J, Gadsboll N. Intracardiac low-energy versus transthoracic high-energy direct-current cardioversion of atrial fibrillation: a randomised comparison. Cardiology. 2003;99(2):72-7. [pmid: 12711881].
Frick M, Darpo B, Ostergren J, et al. The effect of oral magnesium, alone or as an adjuvant to sotalol, after cardioversion in patients with persistent atrial fibrillation. Eur Heart J. 2000;21(14):1177-85. [pmid: 10924301].
Galperin J, Elizari MV, Chiale PA, et al. Efficacy of amiodarone for the termination of chronic atrial fibrillation and maintenance of normal sinus rhythm: a prospective, multicenter, randomized, controlled, double blind trial. J Cardiovasc Pharmacol Ther. 2001;6(4):341-50. [pmid: 11907636].
Gasparini M, Steinberg JS, Arshad A, et al. Resumption of sinus rhythm in patients with heart failure and permanent atrial fibrillation undergoing cardiac resynchronization therapy: a longitudinal observational study. Eur Heart J. 2010;31(8):976-83. [pmid: 20071325].
Gupta D, Earley MJ, Haywood GA, et al. Can atrial fibrillation with a coarse electrocardiographic appearance be treated with catheter ablation of the tricuspid valve-inferior vena cava isthmus? Results of a multicentre randomised controlled trial. Heart. 2007;93(6):688-93. [pmid: 17135218].
Hemels ME, Ruiter JH, Molhoek GP, et al. Right atrial preventive and antitachycardia pacing for prevention of paroxysmal atrial fibrillation in patients without bradycardia: a randomized study. Europace. 2008;10(3):306-13. [pmid: 18245199].
Hohnloser SH, Crijns HJ, van Eickels M, et al. Effect of dronedarone on cardiovascular events in atrial fibrillation. N Engl J Med. 2009;360(7):668-78. [pmid: 19213680].
Jong GP, Chang MH, Chang TC, et al. Long-term efficacy and safety of very-low-dose amiodarone treatment for the maintenance of sinus rhythm in patients with chronic atrial fibrillation after successful direct-current cardioversion. Chin Med J (Engl). 2006;119(24):2030-5. [pmid: 17199952].
Kanoupakis EM, Kochiadakis GE, Manios EG, et al. Pharmacological cardioversion of recent onset atrial fibrillation with intravenous amiodarone in patients receiving long-term amiodarone therapy: is it reasonable?. J Interv Card Electrophysiol. 2003;8(1):19-26. [pmid: 12652173].
Katritsis DG, Giazitzoglou E, Zografos T, et al. Rapid pulmonary vein isolation combined with autonomic ganglia modification: a randomized study. Heart Rhythm. 2011;8(5):672-8. [pmid: 21199686].
Khitri AR, Aliot EM, Capucci A, et al. Celivarone for maintenance of sinus rhythm and conversion of atrial fibrillation/flutter. J Cardiovasc Electrophysiol. 2012;23(5):462-72. [pmid: 22171925].
Kirchhof P, Andresen D, Bosch R, et al. Short-term versus long-term antiarrhythmic drug treatment after cardioversion of atrial fibrillation (Flec-SL): a prospective, randomised, open-label, blinded endpoint assessment trial. Lancet. 2012;380(9838):238-46. [pmid: 22713626].
Kistler PM, Rajappan K, Harris S, et al. The impact of image integration on catheter ablation of atrial fibrillation using electroanatomic mapping: a prospective randomized study. Eur Heart J. 2008;29(24):3029-36. [pmid: 18931059].
Kochiadakis GE, Igoumenidis NE, Hamilos ME, et al. A comparative study of the efficacy and safety of procainamide versus propafenone versus amiodarone for the conversion of recent-onset atrial fibrillation. Am J Cardiol. 2007;99(12):1721-5. [pmid: 17560882].
Kochiadakis GE, Kanoupakis EM, Igoumenidis NE, et al. Efficacy and safety of oral amiodarone in controlling heart rate in patients with persistent atrial fibrillation who have undergone digitalisation. Hellenic J Cardiol. 2005;46(5):336-40. [pmid: 16295942].
Kosior DA, Kochanowski J, Scislo P, et al. Efficacy and tolerability of oral propafenone versus quinidine in the treatment of recent onset atrial fibrillation: A randomized, prospective study. Cardiol J. 2009;16(6):521-7. [pmid: 19950088].
Kozluk E, Gawrysiak M, Lodzinski P, et al. The LocaLisa system as the key to shortening the procedure duration and fluoroscopy time during ablation of atrial fibrillation. Kardiol Pol. 2008;66(6):624-9. discussion 630-1. [pmid: 18626831].
Kuhlkamp V, Schirdewan A, Stangl K, et al. Use of metoprolol CR/XL to maintain sinus rhythm after conversion from persistent atrial fibrillation: a randomized, double-blind, placebo-controlled study. J Am Coll Cardiol. 2000;36(1):139-46. [pmid: 10898425].
Kumagai K, Ogawa M, Noguchi H, et al. Comparison of 2 mapping strategies for pulmonary vein isolation. Circ J. 2005;69(12):1496-502. [pmid: 16308498].
Lin YJ, Chang SL, Lo LW, et al. A prospective, randomized comparison of modified pulmonary vein isolation versus conventional pulmonary vein isolation in patients with paroxysmal atrial fibrillation. J Cardiovasc Electrophysiol. 2012. [pmid: 22702369].
Lindeboom JE, Kingma JH, Crijns HJ, et al. Efficacy and safety of intravenous dofetilide for rapid termination of atrial fibrillation and atrial flutter. Am J Cardiol. 2000;85(8):1031-3. [pmid: 10760352].
Liu X, Dong J, Mavrakis HE, et al. Achievement of pulmonary vein isolation in patients undergoing circumferential pulmonary vein ablation: a randomized comparison between two different isolation approaches. Journal of Cardiovascular Electrophysiology. 2006;17(12):1263-70. [pmid: 17239094].
Lombardi F, Borggrefe M, Ruzyllo W, et al. Azimilide vs. placebo and sotalol for persistent atrial fibrillation: the A-COMET-II (Azimilide-CardiOversion MaintEnance Trial-II) trial. Eur Heart J. 2006;27(18):2224-31. [pmid: 16935870].
Luedorff G, Grove R, Kowalski M, et al. Impact of chronic atrial fibrillation in patients with severe heart failure and indication for CRT - Data of two registries with 711 patients (1999-2006 and 2007-6/2008). Herzschrittmacherther Elektrophysiol. 2011:1-7.
Martinez-Marcos FJ, Garcia-Garmendia JL, Ortega-Carpio A, et al. Comparison of intravenous flecainide, propafenone, and amiodarone for conversion of acute atrial fibrillation to sinus rhythm. Am J Cardiol. 2000;86(9):950-3. [pmid: 11053705].
Matsuo S, Yamane T, Date T, et al. Completion of mitral isthmus ablation using a steerable sheath: Prospective randomized comparison with a nonsteerable sheath. Journal of Cardiovascular Electrophysiology. 2011;22(12):1331-1338. [pmid: 21649779].
Mazza A, Fera MS, Pugliese M, et al. Biphasic transoesophageal vs. transthoracic electrical cardioversion of persistent atrial fibrillation. J Cardiovasc Med (Hagerstown). 2006;7(8):594-600. [pmid: 16858238].
Meinertz T, Lip GY, Lombardi F, et al. Efficacy and safety of propafenone sustained release in the prophylaxis of symptomatic paroxysmal atrial fibrillation (The European Rythmol/Rytmonorm Atrial Fibrillation Trial [ERAFT] Study). Am J Cardiol. 2002;90(12):1300-6. [pmid: 12480038].
Menezes Ada S Jr., Martinelli Filho M, Menezes CC, et al. Effects of the association of dual-site dynamic atrial overdrive and atenolol in preventing recurrent atrial fibrillation. Arq Bras Cardiol. 2007;88(1):1-7. [pmid: 17364111].
Natale A, Newby KH, Pisano E, et al. Prospective randomized comparison of antiarrhythmic therapy versus first-line radiofrequency ablation in patients with atrial flutter. J Am Coll Cardiol. 2000;35(7):1898-904. [pmid: 10841241].
Ogawa S, Yamashita T, Yamazaki T, et al. Optimal treatment strategy for patients with paroxysmal atrial fibrillation: J-RHYTHM Study. Circ J. 2009;73(2):242-8. [pmid: 19060419].
O'Hara GE, Philippon F, Gilbert M, et al. Combined Administration of Quinidine and Propafenone for Atrial Fibrillation: The CAQ-PAF Study. J Clin Pharmacol. 2011. [pmid: 21508180].
Orlov MV, Gardin JM, Slawsky M, et al. Biventricular pacing improves cardiac function and prevents further left atrial remodeling in patients with symptomatic atrial fibrillation after atrioventricular node ablation. Am Heart J. 2010;159(2):264-70. [pmid: 20152225].
Padeletti L, Botto G, Spampinato A, et al. Prevention of paroxysmal atrial fibrillation in patients with sinus bradycardia: role of right atrial linear ablation and pacing site. J Cardiovasc Electrophysiol. 2003;14(7):733-8. [pmid: 12930254].
Padeletti L, Muto C, Maounis T, et al. Atrial fibrillation in recipients of cardiac resynchronization therapy device: 1-year results of the randomized MASCOT trial. Am Heart J. 2008;156(3):520-6. [pmid: 18760135].
Page RL, Connolly SJ, Crijns HJ, et al. Rhythm- and rate-controlling effects of dronedarone in patients with atrial fibrillation (from the ATHENA trial). Am J Cardiol. 2011;107(7):1019-22. [pmid: 21296333].
Patten M, Maas R, Bauer P, et al. Suppression of paroxysmal atrial tachyarrhythmias--results of the SOPAT trial. Eur Heart J. 2004;25(16):1395-404. [pmid: 15321697].
Patten M, Maas R, Karim A, et al. Event-recorder monitoring in the diagnosis of atrial fibrillation in symptomatic patients: subanalysis of the SOPAT trial. J Cardiovasc Electrophysiol. 2006;17(11):1216-20. [pmid: 16987384].
Peuhkurinen K, Niemela M, Ylitalo A, et al. Effectiveness of amiodarone as a single oral dose for recent-onset atrial fibrillation. Am J Cardiol. 2000;85(4):462-5. [pmid: 10728951].
Piorkowski C, Eitel C, Rolf S, et al. Steerable versus nonsteerable sheath technology in atrial fibrillation ablation: a prospective, randomized study. Circ Arrhythm Electrophysiol. 2011;4(2):157-65. [pmid: 21248246].
Pritchett EL, Page RL, Carlson M, et al. Efficacy and safety of sustained-release propafenone (propafenone SR) for patients with atrial fibrillation. Am J Cardiol. 2003;92(8):941-6. [pmid: 14556870].
Ramdat Misier AR, Beukema WP, Oude Luttikhuis HA, et al. Multisite atrial pacing: an option for atrial fibrillation prevention? Preliminary results of the Dutch Dual-site Right Atrial Pacing for Prevention of Atrial Fibrillation study. Am J Cardiol. 2000;86(9A):20K-24K. [pmid: 11084095].
Reisinger J, Gatterer E, Lang W, et al. Flecainide versus ibutilide for immediate cardioversion of atrial fibrillation of recent onset. Eur Heart J. 2004;25(15):1318-24. [pmid: 15288159].
Sairaku A, Yoshida Y, Kamiya H, et al. High-frequency stimulation of the atria increases early recurrence following pulmonary vein isolation in patients with persistent atrial fibrillation. Heart Rhythm. 2012. [pmid: 22583843].
Santini L, Gallagher MM, Papavasileiou LP, et al. Transthoracic versus transesophageal cardioversion of atrial fibrillation under light sedation: a prospective randomized trial. Pacing Clin Electrophysiol. 2007;30(12):1469-75. [pmid: 18070300].
Schmidt B, Gunawardene M, Bordignon S, et al. The more the better?: High dose versus low dose laser balloon ablation for pulmonary vein isolation. Journal of Cardiovascular Electrophysiology. 2012;23(6):684.
Schwartzman D, Harvey MN, Hoyt RH, et al. Utility of adjunctive single oral bolus propafenone therapy in patients with atrial defibrillators. Europace. 2006;8(3):211-5. [pmid: 16627442].
Singh BN, Connolly SJ, Crijns HJ, et al. Dronedarone for maintenance of sinus rhythm in atrial fibrillation or flutter. N Engl J Med. 2007;357(10):987-99. [pmid: 17804843].
Singh S, Zoble RG, Yellen L, et al. Efficacy and safety of oral dofetilide in converting to and maintaining sinus rhythm in patients with chronic atrial fibrillation or atrial flutter: the symptomatic atrial fibrillation investigative research on dofetilide (SAFIRE-D) study. Circulation. 2000;102(19):2385-90. [pmid: 11067793].
Singh SN, Tang XC, Singh BN, et al. Quality of life and exercise performance in patients in sinus rhythm versus persistent atrial fibrillation: a Veterans Affairs Cooperative Studies Program Substudy. J Am Coll Cardiol. 2006;48(4):721-30. [pmid: 16904540].
Sporton SC, Earley MJ, Nathan AW, et al. Electroanatomic versus fluoroscopic mapping for catheter ablation procedures: a prospective randomized study. J Cardiovasc Electrophysiol. 2004;15(3):310-5. [pmid: 15030422].
Sra J, Narayan G, Krum D, et al. Computed tomography-fluoroscopy image integration-guided catheter ablation of atrial fibrillation. Journal of Cardiovascular Electrophysiology. 2007;18(4):409-14. [pmid: 17284262].
Stabile G, De Simone A, Turco P, et al. Response to flecainide infusion predicts long-term success of hybrid pharmacologic and ablation therapy in patients with atrial fibrillation. J Am Coll Cardiol. 2001;37(6):1639-44. [pmid: 11345378].
Suleiman M, Koestler C, Lerman A, et al. Atorvastatin for prevention of atrial fibrillation recurrence following pulmonary vein isolation: A double-blind, placebo-controlled, randomized trial. Heart Rhythm. 2012;9(2):172-8. [pmid: 21920481].
Sultan A, Steven D, Rostock T, et al. Intravenous Administration of Magnesium and Potassium Solution Lowers Energy Levels and Increases Success Rates Electrically Cardioverting Atrial Fibrillation. J Cardiovasc Electrophysiol. 2011. [pmid: 21815963].
Tamborero D, Mont L, Berruezo A, et al. Circumferential pulmonary vein ablation: does use of a circular mapping catheter improve results? A prospective randomized study. Heart Rhythm. 2010;7(5):612-8. [pmid: 20193794].
Torp-Pedersen C, Crijns HJ, Gaudin C, et al. Impact of dronedarone on hospitalization burden in patients with atrial fibrillation: results from the ATHENA study. Europace. 2011;13(8):1118-26. [pmid: 21576129].
Torp-Pedersen C, Raev DH, Dickinson G, et al. A randomized, placebo-controlled study of vernakalant (oral) for the prevention of atrial fibrillation recurrence after cardioversion. Circ Arrhythm Electrophysiol. 2011;4(5):637-43. [pmid: 21841207].
Touboul P, Brugada J, Capucci A, et al. Dronedarone for prevention of atrial fibrillation: a dose-ranging study. Eur Heart J. 2003;24(16):1481-7. [pmid: 12919771].
Tveit A, Grundvold I, Olufsen M, et al. Candesartan in the prevention of relapsing atrial fibrillation. Int J Cardiol. 2007;120(1):85-91. [pmid: 17113170].
Ueng KC, Tsai TP, Yu WC, et al. Use of enalapril to facilitate sinus rhythm maintenance after external cardioversion of long-standing persistent atrial fibrillation. Results of a prospective and controlled study. Eur Heart J. 2003;24(23):2090-8. [pmid: 14643269].
Vardas PE, Kochiadakis GE, Igoumenidis NE, et al. Amiodarone as a first-choice drug for restoring sinus rhythm in patients with atrial fibrillation: a randomized, controlled study. Chest. 2000;117(6):1538-45. [pmid: 10858380].
Vasconcelos JT, Scanavacca MI, Sampaio RO, et al. Surgical treatment of atrial fibrillation through isolation of the left atrial posterior wall in patients with chronic rheumatic mitral valve disease. A randomized study with control group. Arquivos Brasileiros de Cardiologia. 2004;83(3):211-8. 203. 10. [pmid: 15375469].
Wang JG, Li Y, Shi JH, et al. Treatment of long-lasting persistent atrial fibrillation using minimally invasive surgery combined with irbesartan. Ann Thorac Surg. 2011;91(4):1183-9. [pmid: 21440143].
Wang W, Buehler D, Feng XD, et al. Continuous biatrial pacing to prevent early recurrence of atrial fibrillation after the Maze procedure. J Thorac Cardiovasc Surg. 2011;142(5):989-994. [pmid: 21864856].
Xanthos T, Prapa V, Papadimitriou D, et al. Comparative study of intravenous amiodarone and procainamide in the treatment of atrial fibrillation of recent onset. Minerva Cardioangiol. 2007;55(4):433-41. [pmid: 17653020].
Yalcin R, Kaya MG, Ozdemir M, et al. Prospective randomized trial of transthoracic versus low-energy transvenous internal cardioversion in persistent atrial fibrillation. Acta Cardiol. 2004;59(5):521-6. [pmid: 15529558].
Yamase M, Nakazato Y, Daida H. Effectiveness of amiodarone versus bepridil in achieving conversion to sinus rhythm in patients with persistent atrial fibrillation: a randomised trial. Heart. 2012;98(14):1067-71. [pmid: 22689712].
Yamashita T, Inoue H, Okumura K, et al. Randomized trial of angiotensin II-receptor blocker vs. dihydropiridine calcium channel blocker in the treatment of paroxysmal atrial fibrillation with hypertension (J-RHYTHM II study). Europace. 2011;13(4):473-9. [pmid: 21148662].
Yamashita T, Ogawa S, Sato T, et al. Dose-response effects of bepridil in patients with persistent atrial fibrillation monitored with transtelephonic electrocardiograms: a multicenter, randomized, placebo-controlled,double-blind study (J-BAF Study). Circ J. 2009;73(6):1020-7. [pmid: 19359813].
Yin Y, Dalal D, Liu Z, et al. Prospective randomized study comparing amiodarone vs. amiodarone plus losartan vs. amiodarone plus perindopril for the prevention of atrial fibrillation recurrence in patients with lone paroxysmal atrial fibrillation. Eur Heart J. 2006;27(15):1841-6. [pmid: 16825288].
Yoshida T, Niwano S, Inuo K, et al. Bepridil prevents paroxysmal atrial fibrillation by a class III antiarrhythmic drug effect. Pacing Clin Electrophysiol. 2003;26(1 Pt 2):314-7. [pmid: 12687836].
Zhang N, Guo JH, Zhang H, et al. Comparison of intravenous ibutilide vs. propafenone for rapid termination of recent onset atrial fibrillation. Int. J Clin Pract. 2005;59(12):1395-400. [pmid: 16351670].

## No Outcomes of Interest

Ambler JJ, Deakin CD. A randomised controlled trial of the effect of biphasic or monophasic waveform on the incidence and severity of cutaneous burns following external direct current cardioversion. Resuscitation. 2006;71(3):293-300. [pmid: 16996194].
Brignole M, Botto G, Mont L, et al. Cardiac resynchronization therapy in patients undergoing atrioventricular junction ablation for permanent atrial fibrillation: A randomized trial. Eur Heart J. 2011;32(19):2420-2429. [pmid: 21606084].
DeCara JM, Pollak A, Dubrey S, et al. Positive atrial inotropic effect of dofetilide after cardioversion of atrial fibrillation or flutter. Am J Cardiol. 2000;86(6):685-8. A8. [pmid: 10980226].
Deneer VH, Lie AHL, Kingma JH, et al. Absorption kinetics and pharmacodynamics of two oral dosage forms of flecainide in patients with an episode of paroxysmal atrial fibrillation. Eur J Clin Pharmacol. 2004;60(10):693-701. [pmid: 15619132].
Ferreira AM, Adragao P, Cavaco DM, et al. Benefit of cardiac resynchronization therapy in atrial fibrillation patients vs. patients in sinus rhythm: the role of atrioventricular junction ablation. Europace. 2008;10(7):809-15. [pmid: 18511438].
Fung JW, Chan SK, Yeung LY, et al. Is beta-blockade useful in heart failure patients with atrial fibrillation? An analysis of data from two previously completed prospective trials. Eur J Heart Fail. 2002;4(4):489-94. [pmid: 12167389].
Leclercq C, Victor F, Alonso C, et al. Comparative effects of permanent biventricular pacing for refractory heart failure in patients with stable sinus rhythm or chronic atrial fibrillation. American Journal of Cardiology. 2000;85(9):1154-6. A9. [pmid: 10781772].
Koch L, Haeusler KG, Herm J, et al. Mesh ablator vs. cryoballoon pulmonary vein ablation of symptomatic paroxysmal atrial fibrillation: results of the MACPAF study. Europace. 2012. [pmid: 22523379].
Pappone C, Manguso F, Vicedomini G, et al. Prevention of iatrogenic atrial tachycardia after ablation of atrial fibrillation: a prospective randomized study comparing circumferential pulmonary vein ablation with a modified approach. Circulation. 2004;110(19):3036-42. [pmid: 15520310].
Saxon LA, Greenfield RA, Crandall BG, et al. Results of the multicenter RENEWAL 3 AVT clinical study of cardiac resynchronization defibrillator therapy in patients with paroxysmal atrial.
van Breugel NH, Bidar E, Essers BA, et al. Cost-effectiveness of ablation surgery in patients with atrial fibrillation undergoing cardiac surgery fibrillation. Interact Cardiovasc Thorac Surg. 2011;12(3):394-8. [pmid: 21148666]. J Cardiovasc Electrophysiol. 2006;17(5):520-5. [pmid: 16684026].

## Not an RCT for KQs 1, 3, 4, 5, or 6 (Observational Studies Also Allowed for KQ 5 if Addressing CRT)

Al-Khatib SM, Shaw LK, Lee KL, et al. Is rhythm control superior to rate control in patients with atrial fibrillation and congestive heart failure?. Am J Cardiol. 2004;94(6):797-800. [pmid: 15374794].
Alcaraz R, Rieta JJ, Hornero F. Non-invasive atrial fibrillation organization follow-up under successive attempts of electrical cardioversion. Med Biol Eng Comput. 2009;47(12):1247-55. [pmid: 19730915].
Amit G, Rosen A, Wagshal AB, et al. Efficacy of substituting innovator propafenone for its generic formulation in patients with atrial fibrillation. Am J Cardiol. 2004;93(12):1558-60. [pmid: 15194037].
Cappato R, Calkins H, Chen SA, et al. Updated worldwide survey on the methods, efficacy, and safety of catheter ablation for human atrial fibrillation. Circ Arrhythm Electrophysiol. 2010;3(1):32-8. [pmid: 19995881].
Cappato R, Calkins H, Chen SA, et al. Worldwide survey on the methods, efficacy, and safety of catheter ablation for human atrial fibrillation. Circulation. 2005;111(9):1100-5. [pmid: 15723973].
Capucci A, Villani GQ, Piepoli MF. Reproducible efficacy of loading oral propafenone in restoring sinus rhythm in patients with paroxysmal atrial fibrillation. Am J Cardiol. 2003;92(11):1345-7. [pmid: 14636919].
Cha YM, Friedman PA, Asirvatham SJ, et al. Catheter ablation for atrial fibrillation in patients with obesity. Circulation. 2008;117(20):2583-90. [pmid: 18474813].
Chang SL, Tai CT, Lin YJ, et al. Comparison of cooled-tip versus 4-mm-tip catheter in the efficacy of acute ablative tissue injury during circumferential pulmonary vein isolation. J Cardiovasc Electrophysiol. 2009;20(10):1113-8. [pmid: 19563365].
Chang SL, Tsao HM, Lin YJ, et al. Characteristics and Significance of Very Early Recurrence of Atrial Fibrillation After Catheter Ablation. J Cardiovasc Electrophysiol. 2011;22(11):1193-1198. [pmid: 21615812].
Chang SL, Tuan TC, Tai CT, et al. Comparison of outcome in catheter ablation of atrial fibrillation in patients with versus without the metabolic syndrome. Am J Cardiol. 2009;103(1):67-72. [pmid: 19101232].
Chao TF, Lin YJ, Chang SL, et al. Associations between renal function, atrial substrate properties and outcome of catheter ablation in patients with paroxysmal atrial fibrillation. Circ J. 2011;75(10):2326-32. [pmid: 21778593].
Chao TF, Suenari K, Chang SL, et al. Atrial substrate properties and outcome of catheter ablation in patients with paroxysmal atrial fibrillation associated with diabetes mellitus or impaired fasting glucose. Am J Cardiol. 2010;106(11):1615-20. [pmid: 21094363].
Chen MC, Chang JP, Guo GB, et al. Atrial size reduction as a predictor of the success of radiofrequency maze procedure for chronic atrial fibrillation in patients undergoing concomitant valvular surgery. J Cardiovasc Electrophysiol. 2001;12(8):867-74. [pmid: 11513435].
Chiladakis JA, Kalogeropoulos A, Patsouras N, et al. Ibutilide added to propafenone for the conversion of atrial fibrillation and atrial flutter. J Am Coll Cardiol. 2004;44(4):859-63. [pmid: 15312872].
Chilukuri K, Dalal D, Marine JE, et al. Predictive value of obstructive sleep apnoea assessed by the Berlin Questionnaire for outcomes after the catheter ablation of atrial fibrillation. Europace. 2009;11(7):896-901. [pmid: 19297363].
Chugh A, Oral H, Lemola K, et al. Prevalence, mechanisms, and clinical significance of macroreentrant atrial tachycardia during and following left atrial ablation for atrial fibrillation. Heart Rhythm. 2005;2(5):464-71. [pmid: 15840468].
Corrado A, Patel D, Riedlbauchova L, et al. Efficacy, safety, and outcome of atrial fibrillation ablation in septuagenarians. J Cardiovasc Electrophysiol. 2008;19(8):807-11. [pmid: 18363688].
Crawford T, Chugh A, Good E, et al. Clinical value of noninducibility by high-dose isoproterenol versus rapid atrial pacing after catheter ablation of paroxysmal atrial fibrillation. J Cardiovasc Electrophysiol. 2010;21(1):13-20. [pmid: 19682170].
Danicek V, Theodorovich N, Bar-Chaim S, et al. Sinus rhythm restoration after atrial fibrillation: the clinical value of N-terminal pro-BNP measurements. Pacing Clin Electrophysiol. 2008;31(8):955-60. [pmid: 18684250].
Daoud EG, Weiss R, Augostini R, et al. Proarrhythmia of circumferential left atrial lesions for management of atrial fibrillation. J Cardiovasc Electrophysiol. 2006;17(2):157-65. [pmid: 16533253].
Das MK, Cheriparambil K, Bedi A, et al. Cardioversion of atrial fibrillation with ibutilide: when is it most effective?. Clin Cardiol. 2002;25(9):411-5. [pmid: 12269519].
den Uijl DW, Delgado V, Bertini M, et al. Impact of left atrial fibrosis and left atrial size on the outcome of catheter ablation for atrial fibrillation. Heart. 2011;97(22):1847-51. [pmid: 21357370].
Deneke T, Khargi K, Lemke B, et al. Intra-operative cooled-tip radiofrequency linear atrial ablation to treat permanent atrial fibrillation. Eur Heart J. 2007;28(23):2909-14. [pmid: 17956873].
Edgerton JR, Mahoney C, Mack MJ, et al. Long-term monitoring after surgical ablation for atrial fibrillation: how much is enough?. J Thorac Cardiovasc Surg. 2011;142(1):162-5. [pmid: 21377697].
Eitel C, Hindricks G, Sommer P, et al. Circumferential pulmonary vein isolation and linear left atrial ablation as a single-catheter technique to achieve bidirectional conduction block: the pace-and-ablate approach. Heart Rhythm. 2010;7(2):157-64. [pmid: 20036199].
Elhendy A, Gentile F, Khandheria BK, et al. Safety of electrical cardioversion in patients with previous embolic events. Mayo Clin Proc. 2001;76(4):364-8. [pmid: 11322351].
Ermis C, Zhu AX, Sinha S, et al. Efficacy of biphasic waveform cardioversion for atrial fibrillation and atrial flutter compared with conventional monophasic waveforms. Am J Cardiol. 2002;90(8):891-2. [pmid: 12372583].
Figueiredo E, Veloso HH, Paola AA. Initial energy for external electrical cardioversion of atrial fibrillation. Arq Bras Cardiol. 2002;79(2):129-38. [pmid: 12219186].
Fragakis N, Papadopoulos N, Papanastasiou S, et al. Efficacy and safety of ibutilide for cardioversion of atrial flutter and fibrillation in patients receiving amiodarone or propafenone. Pacing Clin Electrophysiol. 2005;28(9):954-61. [pmid: 16176535].
Gulizia M, Mangiameli S, Chiaranda G, et al. Design and rationale of a randomized study to compare amiodarone and Class IC anti-arrhythmic drugs in terms of atrial fibrillation treatment efficacy in patients paced for sinus node disease: the PITAGORA trial. Europace. 2006;8(4):302-5. [pmid: 16627459].
Hofmann R, Wimmer G, Leisch F. Intravenous amiodarone bolus immediately controls heart rate in patients with atrial fibrillation accompanied by severe congestive heart failure. Heart. 2000;84(6):635. [pmid: 11083743].
Hossack M. Towards evidence based emergency medicine: best BETs from the Manchester Royal Infirmary. BET 4. Beta-blockers or digoxin for rate control of acute atrial fibrillation in the emergency department. Emerg Med J. 2009;26(1):61. [pmid: 19104108].
Kottkamp H, Hindricks G, Autschbach R, et al. Specific linear left atrial lesions in atrial fibrillation: intraoperative radiofrequency ablation using minimally invasive surgical techniques. J Am Coll Cardiol. 2002;40(3):475-80. [pmid: 12142113].
Kottkamp H, Tanner H, Kobza R, et al. Time courses and quantitative analysis of atrial fibrillation episode number and duration after circular plus linear left atrial lesions: trigger elimination or substrate modification: early or delayed cure?. J Am Coll Cardiol. 2004;44(4):869-77. [pmid: 15312874].
Krakor R, Chares M, Schneider J, et al. Mid-term results of endoscopic mitral valve repair in combination with endocardial or epicardial ablation. Eur J Cardiothorac Surg. 2011;40(3):e125-9. [pmid: 21658967].
Lee G, Sparks PB, Morton JB, et al. Low risk of major complications associated with pulmonary vein antral isolation for atrial fibrillation: results of 500 consecutive ablation procedures in patients with low prevalence of structural heart disease from a single center. J Cardiovasc Electrophysiol. 2011;22(2):163-8. [pmid: 20731742].
Lellouche N, Jais P, Nault I, et al. Early recurrences after atrial fibrillation ablation: prognostic value and effect of early reablation. J Cardiovasc Electrophysiol. 2008;19(6):599-605. [pmid: 18462321].
Li H, Riedel R, Oldemeyer JB, et al. Comparison of recurrence rates after direct-current cardioversion for new-onset atrial fibrillation in patients receiving versus those not receiving rhythm-control drug therapy. Am J Cardiol. 2004;93(1):45-8. [pmid: 14697464].
Liu Z, Ling Z, Su L, et al. The effect of different treatment strategies on left atrial size in patients with lone paroxysmal atrial fibrillation-a prospective cohort study. J Interv Card Electrophysiol. 2008;23(3):167-73. [pmid: 18810622].
Oakes RS, Badger TJ, Kholmovski EG, et al. Detection and quantification of left atrial structural remodeling with delayed-enhancement magnetic resonance imaging in patients with atrial fibrillation. Circulation. 2009;119(13):1758-67. [pmid: 19307477].
Queiroga A, Marshall HJ, Clune M, et al. Ablate and pace revisited: long term survival and predictors of permanent atrial fibrillation. Heart. 2003;89(9):1035-8. [pmid: 12923021].
Rivard L, Khairy P, MacLe L, et al. Improved outcome following restoration of sinus rhythm prior to catheter ablation of persistent atrial fibrillation: A comparative multicenter study. Journal of Interventional Cardiac Electrophysiology. 2012;33(3):297.
Verma A, Patel D, Famy T, et al. Efficacy of adjuvant anterior left atrial ablation during intracardiac echocardiography-guided pulmonary vein antrum isolation for atrial fibrillation. J Cardiovasc Electrophysiol. 2007;18(2):151-6. [pmid: 17338763].