# Exact Search Strings

## PubMed^®^ Search Strategy (Final Search Date August 1, 2012)

KQ 1—What are the comparative safety and effectiveness of pharmacological agents used for ventricular rate control in patients with atrial fibrillation? Do the comparative safety and effectiveness of these therapies differ among specific patient subgroups of interest?

Set # | Terms
#1 | “Atrial Fibrillation”[Mesh] OR “atrial fibrillation”[tiab] OR (atrial[tiab] AND fibrillation[tiab]) OR afib[tiab] OR “atrial flutter”[MeSH Terms] OR “atrial flutter”[tiab]
#2 | ”Anti-Arrhythmia Agents”[Mesh] OR “Anti-Arrhythmia Agents”[Pharmacological Action] OR ((antiarrhythmic[tiab] OR antiarrhythmia[tiab]) AND (agent[tiab] OR agents[tiab] OR drug[tiab] OR drugs[tiab])) OR “metoprolol”[MeSH Terms] OR “metoprolol”[tiab] OR “atenolol”[MeSH Terms] OR “atenolol”[tiab] OR “carvedilol”[Supplementary Concept] OR “carvedilol”[tiab] OR “bisoprolol”[MeSH Terms] OR “bisoprolol”[tiab] OR “timolol”[MeSH Terms] OR “timolol”[tiab] OR “esmolol”[Supplementary Concept] OR “esmolol”[tiab] OR “nebivolol”[Supplementary Concept] OR “nebivolol”[tiab] OR verapamil[tiab] OR “verapamil”[MeSH Terms] OR “diltiazem”[MeSH Terms] OR “diltiazem”[tiab] OR “digoxin”[MeSH Terms] OR “digoxin”[tiab] OR “Adrenergic beta-Antagonists”[Mesh] OR “Adrenergic beta-Antagonists”[Pharmacological Action] OR beta-blocker[tiab] OR beta-blockers[tiab] OR “Calcium Channel Blockers”[Mesh] OR “Calcium Channel Blockers” [Pharmacological Action] OR “Acebutolol”[Mesh] OR acebutolol[tiab] OR “Nadolol”[Mesh] OR Nadolol[tiab] OR “Amiodarone”[Mesh] OR Amiodarone[tiab] OR “dronedarone” [Supplementary Concept] OR dronedarone[tiab]
#3 | “evaluation studies”[Publication Type] OR “evaluation studies as topic”[MeSH Terms] OR “evaluation study”[tw] OR evaluation studies[tw] OR “intervention studies”[MeSH Terms] OR “intervention study”[tw] OR “intervention studies”[tw] OR “case-control studies”[MeSH Terms] OR “case-control”[tw] OR “cohort studies”[MeSH Terms] OR cohort[tw] OR “longitudinal studies”[MeSH Terms] OR “longitudinal”[tw] OR longitudinally[tw] OR “prospective”[tw] OR prospectively[tw] OR “retrospective studies”[MeSH Terms] OR “retrospective”[tw] OR “follow up”[tw] OR “comparative study”[Publication Type] OR “comparative study”[tw] OR systematic[sb] OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[tw] OR “meta-analyses”[tw] OR randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR “drug therapy”[Subheading] OR randomly[tiab] OR trial[tiab] OR groups[tiab] OR Clinical trial[pt] OR “clinical trial”[tw] OR “clinical trials”[tw] NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp])
#4 | #1 AND #2 AND #3
#5 | #4 NOT (animals[mh] NOT humans[mh])
#6 | #5 limits: English, Publication Date from 2000-present

KQ 2—What are the comparative safety and effectiveness of a strict rate-control strategy versus a more lenient rate-control strategy in patients with atrial fibrillation? Do the comparative safety and effectiveness of these therapies differ among specific patient subgroups of interest?

Set # | Terms
#1 | “Atrial Fibrillation”[Mesh] OR “atrial fibrillation”[tiab] OR (atrial[tiab] AND fibrillation[tiab]) OR afib[tiab] OR “atrial flutter”[MeSH Terms] OR “atrial flutter”[tiab]
#2 | ((rate[tiab] OR “heart rate”[MeSH Terms]) AND control[tiab]) AND (strategy[tiab] OR lenient[tiab] OR strict[tiab])
#3 | “evaluation studies”[Publication Type] OR “evaluation studies as topic”[MeSH Terms] OR “evaluation study”[tw] OR evaluation studies[tw] OR “intervention studies”[MeSH Terms] OR “intervention study”[tw] OR “intervention studies”[tw] OR “case-control studies”[MeSH Terms] OR “case-control”[tw] OR “cohort studies”[MeSH Terms] OR cohort[tw] OR “longitudinal studies”[MeSH Terms] OR “longitudinal”[tw] OR longitudinally[tw] OR “prospective”[tw] OR prospectively[tw] OR “retrospective studies”[MeSH Terms] OR “retrospective”[tw] OR “follow up”[tw] OR “comparative study”[Publication Type] OR “comparative study”[tw] OR systematic[sb] OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[tw] OR “meta-analyses”[tw] OR randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR “drug therapy”[Subheading] OR randomly[tiab] OR trial[tiab] OR groups[tiab] OR Clinical trial[pt] OR “clinical trial”[tw] OR “clinical trials”[tw] NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp])
#4 | #1 AND #2 AND #3
#5 | #4 NOT (animals[mh] NOT humans[mh])
#6 | #5 limits: English, Publication Date from 2000-present

KQ 3—What are the comparative safety and effectiveness of newer procedural and other nonpharmacological rate-control therapies compared with pharmacological agents in patients with atrial fibrillation who have failed initial pharmacotherapy? Do the comparative safety and effectiveness of these therapies differ among specific patient subgroups of interest?

Set # | Terms
#1 | “Atrial Fibrillation”[Mesh] OR “atrial fibrillation”[tiab] OR (atrial[tiab] AND fibrillation[tiab]) OR afib[tiab] OR “atrial flutter”[MeSH Terms] OR “atrial flutter”[tiab]
#2 | nonpharmacological[tiab] OR non-pharmacological[tiab] OR “Pacemaker, Artificial”[Mesh] OR pacemaker[tiab] OR (cardiac[tiab] AND (pace[tiab] OR pacing[tiab]) AND artificial[tiab]) OR “Cardiac Pacing, Artificial”[Mesh] OR “Atrioventricular Node”[Mesh] OR AVN[tiab] OR ((atrioventricular[tiab] OR atrio-ventricular[tiab]) AND (nodal[tiab] OR node[tiab])) OR “catheter ablation”[MeSH Terms] OR “catheter ablation”[tiab]
#3 | rate[tiab] OR heart rate[Mesh]
#4 | “evaluation studies”[Publication Type] OR “evaluation studies as topic”[MeSH Terms] OR “evaluation study”[tw] OR evaluation studies[tw] OR “intervention studies”[MeSH Terms] OR “intervention study”[tw] OR “intervention studies”[tw] OR “case-control studies”[MeSH Terms] OR “case-control”[tw] OR “cohort studies”[MeSH Terms] OR cohort[tw] OR “longitudinal studies”[MeSH Terms] OR “longitudinal”[tw] OR longitudinally[tw] OR “prospective”[tw] OR prospectively[tw] OR “retrospective studies”[MeSH Terms] OR “retrospective”[tw] OR “follow up”[tw] OR “comparative study”[Publication Type] OR “comparative study”[tw] OR systematic[subset] OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[tw] OR “meta-analyses”[tw] OR randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR “drug therapy”[Subheading] OR randomly[tiab] OR trial[tiab] OR groups[tiab] OR Clinical trial[pt] OR “clinical trial”[tw] OR “clinical trials”[tw] NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp])
#5 | #1 AND #2 AND #3 AND #4
#6 | #5 NOT (animals[mh] NOT humans[mh])
#7 | #6 limits: English, Publication Date from 2000-present

KQ 4—What are the comparative safety and effectiveness of available antiarrhythmic agents and electrical cardioversion for conversion of atrial fibrillation to sinus rhythm? Do the comparative safety and effectiveness of these therapies differ among specific patient subgroups of interest?

Set # | Terms
#1 | “Atrial Fibrillation”[Mesh] OR “atrial fibrillation”[tiab] OR (atrial[tiab] AND fibrillation[tiab]) OR afib[tiab] OR “atrial flutter”[MeSH Terms] OR “atrial flutter”[tiab]
#2 | “Anti-Arrhythmia Agents”[Mesh] OR “Anti-Arrhythmia Agents”[Pharmacological Action] OR ((antiarrhythmic[tiab] OR antiarrhythmia[tiab]) AND (agent[tiab] OR agents[tiab] OR drug[tiab] OR drugs[tiab])) OR “flecainide”[MeSH Terms] OR “flecainide”[tiab] OR “propafenone”[MeSH Terms] OR “propafenone”[tiab] OR “amiodarone”[MeSH Terms] OR “amiodarone”[tiab] OR “sotalol”[MeSH Terms] OR “sotalol”[tiab] OR “ibutilide”[Supplementary Concept] OR “ibutilide”[tiab] OR “dofetilide”[Supplementary Concept] OR “dofetilide”[tiab] OR “dronedarone”[Supplementary Concept] OR “dronedarone”[tiab] OR “Disopyramide”[Mesh] OR Disopyramide[tiab]
#3 | “electric countershock”[MeSH Terms] OR electrical[tiab] OR cardioversion[tiab]
#4 | “evaluation studies”[Publication Type] OR “evaluation studies as topic”[MeSH Terms] OR “evaluation study”[tw] OR evaluation studies[tw] OR “intervention studies”[MeSH Terms] OR “intervention study”[tw] OR “intervention studies”[tw] OR “case-control studies”[MeSH Terms] OR “case-control”[tw] OR “cohort studies”[MeSH Terms] OR cohort[tw] OR “longitudinal studies”[MeSH Terms] OR “longitudinal”[tw] OR longitudinally[tw] OR “prospective”[tw] OR prospectively[tw] OR “retrospective studies”[MeSH Terms] OR “retrospective”[tw] OR “follow up”[tw] OR “comparative study”[Publication Type] OR “comparative study”[tw] OR systematic[subset] OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[tw] OR “meta-analyses”[tw] OR randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR “drug therapy”[Subheading] OR randomly[tiab] OR trial[tiab] OR groups[tiab] OR Clinical trial[pt] OR “clinical trial”[tw] OR “clinical trials”[tw] NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp])
#5 | #1 AND (#2 OR #3) AND #4
#6 | #5 NOT (animals[mh] NOT humans[mh])
#7 | #6 limits: English, Publication Date from 2000-present

KQ 5—What are the comparative safety and effectiveness of newer procedural rhythm-control therapies, other nonpharmacological rhythm-control therapies, and pharmacological agents for maintenance of sinus rhythm in atrial fibrillation patients? Do the comparative safety and effectiveness of these therapies differ among specific patient subgroups of interest?

Set # | Terms
#1 | “Atrial Fibrillation”[Mesh] OR “atrial fibrillation”[tiab] OR (atrial[tiab] AND fibrillation[tiab]) OR afib[tiab] OR “atrial flutter”[MeSH Terms] OR “atrial flutter”[tiab]
#2 | “Catheter Ablation”[Mesh] OR “Cardiac Resynchronization Therapy”[Mesh] OR non-pharmacological[tiab] OR nonpharmacological[tiab] OR ablation[tiab] OR “surgical maze”[tiab] OR (surgical[tiab] AND maze[tiab]) OR resynchroni*[tiab] OR (ganglionic[tiab] AND ablation[tiab]) OR (ganglionated[tiab] AND ablation[tiab]) OR denervation[tiab] OR “pulmonary vein isolation”[tiab] OR (pulmonary[tiab] AND isolation[tiab]) OR “electric countershock”[MeSH Terms] OR electrical[tiab] OR cardioversion[tiab]
#3 | “Anti-Arrhythmia Agents”[Mesh] OR “Anti-Arrhythmia Agents”[Pharmacological Action] OR ((antiarrhythmic[tiab] OR antiarrhythmia[tiab]) AND (agent[tiab] OR agents[tiab] OR drug[tiab] OR drugs[tiab])) OR “flecainide”[MeSH Terms] OR “flecainide”[tiab] OR “propafenone”[MeSH Terms] OR “propafenone”[tiab] OR “amiodarone”[MeSH Terms] OR “amiodarone”[tiab] OR “sotalol”[MeSH Terms] OR “sotalol”[tiab] OR “ibutilide”[Supplementary Concept] OR “ibutilide”[tiab] OR “dofetilide”[Supplementary Concept] OR “dofetilide”[tiab] OR “dronedarone”[Supplementary Concept] OR “dronedarone”[tiab] OR “Disopyramide”[Mesh] OR Disopyramide[tiab]
#4 | rhythm[tiab]
#5 | “evaluation studies”[Publication Type] OR “evaluation studies as topic”[MeSH Terms] OR “evaluation study”[tw] OR evaluation studies[tw] OR “intervention studies”[MeSH Terms] OR “intervention study”[tw] OR “intervention studies”[tw] OR “case-control studies”[MeSH Terms] OR “case-control”[tw] OR “cohort studies”[MeSH Terms] OR cohort[tw] OR “longitudinal studies”[MeSH Terms] OR “longitudinal”[tw] OR longitudinally[tw] OR “prospective”[tw] OR prospectively[tw] OR “retrospective studies”[MeSH Terms] OR “retrospective”[tw] OR “follow up”[tw] OR “comparative study”[Publication Type] OR “comparative study”[tw] OR systematic[subset] OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[tw] OR “meta-analyses”[tw] OR randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR “drug therapy”[Subheading] OR randomly[tiab] OR trial[tiab] OR groups[tiab] OR Clinical trial[pt] OR “clinical trial”[tw] OR “clinical trials”[tw] NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp])
#6 | #1 AND (#2 OR #3) AND #4 AND #5
#7 | #6 NOT (animals[mh] NOT humans[mh])
#8 | #7 Limits English, Publication Date from 2000-present

KQ 6—What are the comparative safety and effectiveness of rate-control therapies versus rhythm-control therapies in patients with atrial fibrillation? Do the comparative safety and effectiveness of these therapies differ among specific patient subgroups of interest?

Set # | Terms
#1 | “Atrial Fibrillation”[Mesh] OR “atrial fibrillation”[tiab] OR (atrial[tiab] AND fibrillation[tiab]) OR afib[tiab] OR “atrial flutter”[MeSH Terms] OR “atrial flutter”[tiab]
#2 | ((nonpharmacological[tiab] OR non-pharmacological[tiab] OR “Pacemaker, Artificial”[Mesh] OR pacemaker[tiab] OR (cardiac[tiab] AND (pace[tiab] OR pacing[tiab]) AND artificial[tiab]) OR “Cardiac Pacing, Artificial”[Mesh] OR “Atrioventricular Node”[Mesh] OR AVN[tiab] OR ((atrioventricular[tiab] OR atrio-ventricular[tiab]) AND (nodal[tiab] OR node[tiab])) OR “catheter ablation”[MeSH Terms] OR “catheter ablation”[tiab] OR “Anti-Arrhythmia Agents”[Mesh] OR “Anti-Arrhythmia Agents”[Pharmacological Action] OR ((antiarrhythmic[tiab] OR antiarrhythmia[tiab]) AND (agent[tiab] OR agents[tiab] OR drug[tiab] OR drugs[tiab]))) AND (“heart rate”[mesh] OR rate[tiab])) OR “metoprolol”[MeSH Terms] OR “metoprolol”[tiab] OR “atenolol”[MeSH Terms] OR “atenolol”[tiab] OR “carvedilol”[Supplementary Concept] OR “carvedilol”[tiab] OR “bisoprolol”[MeSH Terms] OR “bisoprolol”[tiab] OR “timolol”[MeSH Terms] OR “timolol”[tiab] OR “esmolol”[Supplementary Concept] OR “esmolol”[tiab] OR “nebivolol”[Supplementary Concept] OR “nebivolol”[tiab] OR verapamil[tiab] OR “verapamil”[MeSH Terms] OR “diltiazem”[MeSH Terms] OR “diltiazem”[tiab] OR “digoxin”[MeSH Terms] OR “digoxin”[tiab] OR “Adrenergic beta-Antagonists”[Mesh] OR “Adrenergic beta-Antagonists”[Pharmacological Action] OR beta-blocker[tiab] OR beta-blockers[tiab] OR “Calcium Channel Blockers”[Mesh] OR “Calcium Channel Blockers” [Pharmacological Action] OR “Acebutolol”[Mesh] OR acebutolol[tiab] OR “Nadolol”[Mesh] OR Nadolol[tiab]
#3 | (“Catheter Ablation”[Mesh] OR “Cardiac Resynchronization Therapy”[Mesh] OR non-pharmacological[tiab] OR nonpharmacological[tiab] OR ablation[tiab] OR “surgical maze”[tiab] OR (surgical[tiab] AND maze[tiab]) OR resynchroni*[tiab] OR (ganglionic[tiab] AND ablation[tiab]) OR (ganglionated[tiab] AND ablation[tiab]) OR denervation[tiab] OR “pulmonary vein isolation”[tiab] OR (pulmonary[tiab] AND isolation[tiab]) OR “electric countershock”[MeSH Terms] OR electrical[tiab] OR cardioversion[tiab] OR “Anti-Arrhythmia Agents”[Mesh] OR “Anti-Arrhythmia Agents”[Pharmacological Action] OR ((antiarrhythmic[tiab] OR antiarrhythmia[tiab]) AND (agent[tiab] OR agents[tiab] OR drug[tiab] OR drugs[tiab])) AND rhythm[tiab]) OR “flecainide”[MeSH Terms] OR “flecainide”[tiab] OR “propafenone”[MeSH Terms] OR “propafenone”[tiab] OR “amiodarone”[MeSH Terms] OR “amiodarone”[tiab] OR “sotalol”[MeSH Terms] OR “sotalol”[tiab] OR “ibutilide”[Supplementary Concept] OR “ibutilide”[tiab] OR “dofetilide”[Supplementary Concept] OR “dofetilide”[tiab] OR “dronedarone”[Supplementary Concept] OR “dronedarone”[tiab] OR “Disopyramide”[Mesh] OR Disopyramide[tiab]
#4 | “evaluation studies”[Publication Type] OR “evaluation studies as topic”[MeSH Terms] OR “evaluation study”[tw] OR evaluation studies[tw] OR “intervention studies”[MeSH Terms] OR “intervention study”[tw] OR “intervention studies”[tw] OR “case-control studies”[MeSH Terms] OR “case-control”[tw] OR “cohort studies”[MeSH Terms] OR cohort[tw] OR “longitudinal studies”[MeSH Terms] OR “longitudinal”[tw] OR longitudinally[tw] OR “prospective”[tw] OR prospectively[tw] OR “retrospective studies”[MeSH Terms] OR “retrospective”[tw] OR “follow up”[tw] OR “comparative study”[Publication Type] OR “comparative study”[tw] OR systematic[subset] OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[tw] OR “meta-analyses”[tw] OR randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR “drug therapy”[Subheading] OR randomly[tiab] OR trial[tiab] OR groups[tiab] OR Clinical trial[pt] OR “clinical trial”[tw] OR “clinical trials”[tw] NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp])
#5 | #1 AND #2 AND #3 AND #4
#6 | #5 NOT (animals[mh] NOT humans[mh])
#7 | #6 limits: English, Publication Date from 2000-present

Eliminated KQ^*^ * Note: This KQ was eliminated from the CER for scoping reasons following discussions with AHRQ and the TEP members. Since the KQ was removed after the original PubMed^®^ searches were performed on December 9, 2011, we have included documentation of the search strategy below. This portion of the search was not included in the final search update on August 1, 2012. The results from this search are reflected in the totals depicted in the literature flow diagram. —What are the comparative diagnostic accuracy, diagnostic thinking, therapeutic, and patient outcome efficacy of echocardiographic studies and other clinical parameters for predicting successful conversion, successful ablation, successful maintenance of sinus rhythm, and improved outcomes in patients with atrial fibrillation?

Set # | Terms
#1 | “Atrial Fibrillation”[Mesh] OR “atrial fibrillation”[tiab] OR (atrial[tiab] AND fibrillation[tiab]) OR afib[tiab] OR “atrial flutter”[MeSH Terms] OR “atrial flutter”[tiab]
#2 | predictors[tiab] OR predict[tiab] OR predicting[tiab] OR predicts[tiab] OR predicted[tiab] OR prognosis[tiab] OR prognostic[tiab] OR prognosis[MeSH] OR accurately[tiab] OR accuracy[tiab] OR accurate[tiab] OR reliability[tiab] OR sensitivity[tiab] OR specificity[tiab] OR “Sensitivity and Specificity”[Mesh] OR “Treatment Outcome”[MeSH] OR Diagnosis[MeSH] OR diagnostic[tiab]
#3 | maintain[tiab] OR maintenance[tiab] OR maintained[tiab] OR success[tiab] OR successful[tiab] OR conversion[tiab] OR restoration[tiab] OR restored[tiab]
#4 | “evaluation studies”[Publication Type] OR “evaluation studies as topic”[MeSH Terms] OR “evaluation study”[tw] OR evaluation studies[tw] OR “intervention studies”[MeSH Terms] OR “intervention study”[tw] OR “intervention studies”[tw] OR “case-control studies”[MeSH Terms] OR “case-control”[tw] OR “cohort studies”[MeSH Terms] OR cohort[tw] OR “longitudinal studies”[MeSH Terms] OR “longitudinal”[tw] OR longitudinally[tw] OR “prospective”[tw] OR prospectively[tw] OR “retrospective studies”[MeSH Terms] OR “retrospective”[tw] OR “follow up”[tw] OR “comparative study”[Publication Type] OR “comparative study”[tw] OR systematic[subset] OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[tw] OR “meta-analyses”[tw] OR randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR “drug therapy”[Subheading] OR randomly[tiab] OR trial[tiab] OR groups[tiab] OR Clinical trial[pt] OR “clinical trial”[tw] OR “clinical trials”[tw] NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp])NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp])
#5 | #1 AND #2 AND #3 AND #4
#6 | #5 NOT (animals[mh] NOT humans[mh])
#7 | #6 English, Publication Date from 2000-present

## Embase^®^ Search Strategy (Final Search Date August 1, 2012)

Platform: Embase.com

KQ 1—What are the comparative safety and effectiveness of pharmacological agents used for ventricular rate control in patients with atrial fibrillation? Do the comparative safety and effectiveness of these therapies differ among specific patient subgroups of interest?

Set # | Terms
#1 | ‘heart atrium fibrillation’/exp OR ‘heart atrium flutter’/exp OR “atrial fibrillation”:ab,ti OR (atrial:ab,ti AND fibrillation:ab,ti) OR afib:ab,ti OR “atrial flutter”:ab,ti
#2 | ‘antiarrhythmic agent’/exp OR ‘metoprolol’/exp OR ‘atenolol’/exp OR ‘carvedilol’/exp OR ‘bisoprolol’/exp OR ‘timolol’/exp OR ‘esmolol’/exp OR ‘nebivolol’/exp OR ‘verapamil’/exp OR ‘diltiazem’/exp OR ‘digoxin’/exp OR ‘acetyldigoxin’/exp OR ‘alpha acetyldigoxin’/exp OR ‘metildigoxin’/exp OR ‘digoxigenin’/exp OR ‘beta adrenergic receptor blocking agent’/exp OR ‘calcium channel blocking agent’/exp OR ‘acebutolol’/exp OR ‘nadolol’/exp OR ‘amiodarone’/exp OR ‘dronedarone’/exp OR ((antiarrhythmic:ab,ti OR antiarrhythmia:ab,ti) AND (agent:ab,ti OR agents:ab,ti OR drug:ab,ti OR drugs:ab,ti)) OR metoprolol:ab,ti OR atenolol:ab,ti OR carvedilol:ab,ti OR bisoprolol:ab,ti OR timolol:ab,ti OR esmolol:ab,ti OR nebivolol:ab,ti OR verapamil:ab,ti OR diltiazem:ab,ti OR digoxin:ab,ti OR beta-blocker:ab,ti OR beta-blockers:ab,ti OR acebutolol:ab,ti OR Nadolol:ab,ti OR Amiodarone:ab,ti OR dronedarone:ab,ti
#3 | ‘randomized controlled trial’/exp OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random*:ab,ti OR factorial*:ab,ti OR crossover*:ab,ti OR (cross NEAR/1 over*):ab,ti OR placebo*:ab,ti OR (doubl* NEAR/1 blind*):ab,ti OR (singl* NEAR/1 blind*):ab,ti OR assign*:ab,ti OR allocat*:ab,ti OR volunteer*:ab,ti OR ‘clinical study’/exp OR “clinical trial”:ti,ab OR “clinical trials”:ti,ab OR ‘evaluation’/exp OR “evaluation study”:ab,ti OR “evaluation studies”:ab,ti OR “intervention study”:ab,ti OR “intervention studies”:ab,ti OR “case control”:ab,ti OR ‘cohort analysis’/exp OR cohort:ab,ti OR longitudinal*:ab,ti OR prospective:ab,ti OR prospectively:ab,ti OR retrospective:ab,ti OR ‘follow up’/exp OR “follow up”:ab,ti OR ‘comparative effectiveness’/exp OR ‘comparative study’/exp OR “comparative study”:ab,ti OR “comparative studies”:ab,ti OR ‘evidence based medicine’/exp OR “systematic review”:ab,ti OR “meta-analysis”:ab,ti OR “meta-analyses”:ab,ti NOT (‘case report’/exp OR ‘case study’/exp OR ‘editorial’/exp OR ‘letter’/exp OR ‘note’/exp)
#4 | #1 AND #2 AND #3
#5 | #4, Limits: Humans, English, 2000-present
#6 | #5 AND [embase]/lim NOT [medline]/lim

KQ 2—What are the comparative safety and effectiveness of a strict rate-control strategy versus a more lenient rate-control strategy in patients with atrial fibrillation? Do the comparative safety and effectiveness of these therapies differ among specific patient subgroups of interest?

Set # | Terms
#1 | ‘heart atrium fibrillation’/exp OR ‘heart atrium flutter’/exp OR ‘atrial fibrillation’:ab,ti OR (atrial:ab,ti AND fibrillation:ab,ti) OR afib:ab,ti OR ‘atrial flutter’:ab,ti
#2 | ((rate:ab,ti OR ‘heart rate’/exp) AND control:ab,ti) AND (strategy:ab,ti OR lenient:ab,ti OR strict:ab,ti)
#3 | ‘randomized controlled trial’/exp OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random*:ab,ti OR factorial*:ab,ti OR crossover*:ab,ti OR (cross NEAR/1 over*):ab,ti OR placebo*:ab,ti OR (doubl* NEAR/1 blind*):ab,ti OR (singl* NEAR/1 blind*):ab,ti OR assign*:ab,ti OR allocat*:ab,ti OR volunteer*:ab,ti OR ‘clinical study’/exp OR “clinical trial”:ti,ab OR “clinical trials”:ti,ab OR ‘evaluation’/exp OR “evaluation study”:ab,ti OR “evaluation studies”:ab,ti OR “intervention study”:ab,ti OR “intervention studies”:ab,ti OR “case control”:ab,ti OR ‘cohort analysis’/exp OR cohort:ab,ti OR longitudinal*:ab,ti OR prospective:ab,ti OR prospectively:ab,ti OR retrospective:ab,ti OR ‘follow up’/exp OR “follow up”:ab,ti OR ‘comparative effectiveness’/exp OR ‘comparative study’/exp OR “comparative study”:ab,ti OR “comparative studies”:ab,ti OR ‘evidence based medicine’/exp OR “systematic review”:ab,ti OR “meta-analysis”:ab,ti OR “meta-analyses”:ab,ti NOT (‘case report’/exp OR ‘case study’/exp OR ‘editorial’/exp OR ‘letter’/exp OR ‘note’/exp)
#4 | #1 AND #2 AND #3
#5 | #4, Limits: Humans, English, 2000-present
#6 | #5 AND [embase]/lim NOT [medline]/lim

KQ 3—What are the comparative safety and effectiveness of newer procedural and other nonpharmacological rate-control therapies compared with pharmacological agents in patients with atrial fibrillation who have failed initial pharmacotherapy? Do the comparative safety and effectiveness of these therapies differ among specific patient subgroups of interest?

Set # | Terms
#1 | ‘heart atrium fibrillation’/exp OR ‘heart atrium flutter’/exp OR ‘atrial fibrillation’:ab,ti OR (atrial:ab,ti AND fibrillation:ab,ti) OR afib:ab,ti OR ‘atrial flutter’:ab,ti
#2 | nonpharmacological:ab,ti OR non-pharmacological:ab,ti OR ‘artificial heart pacemaker’/exp OR pacemaker:ab,ti OR (cardiac:ab,ti AND (pace:ab,ti OR pacing:ab,ti) AND artificial:ab,ti) OR ‘heart pacing’/exp OR ‘heart atrioventricular node’/exp OR AVN:ab,ti OR ((atrioventricular:ab,ti OR atrio-ventricular:ab,ti) AND (nodal:ab,ti OR node:ab,ti)) OR ‘catheter ablation’/exp OR “catheter ablation”:ab,ti
#3 | rate:ab,ti OR ‘heart rate’/exp
#4 | ‘randomized controlled trial’/exp OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random*:ab,ti OR factorial*:ab,ti OR crossover*:ab,ti OR (cross NEAR/1 over*):ab,ti OR placebo*:ab,ti OR (doubl* NEAR/1 blind*):ab,ti OR (singl* NEAR/1 blind*):ab,ti OR assign*:ab,ti OR allocat*:ab,ti OR volunteer*:ab,ti OR ‘clinical study’/exp OR “clinical trial”:ti,ab OR “clinical trials”:ti,ab OR ‘evaluation’/exp OR “evaluation study”:ab,ti OR “evaluation studies”:ab,ti OR “intervention study”:ab,ti OR “intervention studies”:ab,ti OR “case control”:ab,ti OR ‘cohort analysis’/exp OR cohort:ab,ti OR longitudinal*:ab,ti OR prospective:ab,ti OR prospectively:ab,ti OR retrospective:ab,ti OR ‘follow up’/exp OR “follow up”:ab,ti OR ‘comparative effectiveness’/exp OR ‘comparative study’/exp OR “comparative study”:ab,ti OR “comparative studies”:ab,ti OR ‘evidence based medicine’/exp OR “systematic review”:ab,ti OR “meta-analysis”:ab,ti OR “meta-analyses”:ab,ti NOT (‘case report’/exp OR ‘case study’/exp OR ‘editorial’/exp OR ‘letter’/exp OR ‘note’/exp)
#5 | #1 AND #2 AND #3 AND #4
#6 | #5, Limits: Humans, English, 2000-present
#7 | #6 AND [embase]/lim NOT [medline]/lim

KQ 4 —What are the comparative safety and effectiveness of available antiarrhythmic agents and electrical cardioversion for conversion of atrial fibrillation to sinus rhythm? Do the comparative safety and effectiveness of these therapies differ among specific patient subgroups of interest?

Set # | Terms
#1 | ‘heart atrium fibrillation’/exp OR ‘heart atrium flutter’/exp OR ‘atrial fibrillation’:ab,ti OR (atrial:ab,ti AND fibrillation:ab,ti) OR afib:ab,ti OR ‘atrial flutter’:ab,ti
#2 | ‘antiarrhythmic agent’/exp OR ((antiarrhythmic:ab,ti OR antiarrhythmia:ab,ti) AND (agent:ab,ti OR agents:ab,ti OR drug:ab,ti OR drugs:ab,ti)) OR ‘flecainide’/exp OR flecainide:ab,ti OR ‘propafenone’/exp OR propafenone:ab,ti OR ‘amiodarone’/exp OR amiodarone:ab,ti OR ‘sotalol’/exp OR sotalol:ab,ti OR ‘ibutilide’/exp OR ibutilide:ab,ti OR ‘dofetilide’/exp OR dofetilide:ab,ti OR ‘dronedarone’/exp OR dronedarone:ab,ti OR ‘disopyramide’/exp OR Disopyramide:ab,ti
#3 | ‘cardioversion’/exp OR ‘defibrillation’/exp OR electrical:ab,ti OR cardioversion:ab,ti
#4 | ‘randomized controlled trial’/exp OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random*:ab,ti OR factorial*:ab,ti OR crossover*:ab,ti OR (cross NEAR/1 over*):ab,ti OR placebo*:ab,ti OR (doubl* NEAR/1 blind*):ab,ti OR (singl* NEAR/1 blind*):ab,ti OR assign*:ab,ti OR allocat*:ab,ti OR volunteer*:ab,ti OR ‘clinical study’/exp OR “clinical trial”:ti,ab OR “clinical trials”:ti,ab OR ‘evaluation’/exp OR “evaluation study”:ab,ti OR “evaluation studies”:ab,ti OR “intervention study”:ab,ti OR “intervention studies”:ab,ti OR “case control”:ab,ti OR ‘cohort analysis’/exp OR cohort:ab,ti OR longitudinal*:ab,ti OR prospective:ab,ti OR prospectively:ab,ti OR retrospective:ab,ti OR ‘follow up’/exp OR “follow up”:ab,ti OR ‘comparative effectiveness’/exp OR ‘comparative study’/exp OR “comparative study”:ab,ti OR “comparative studies”:ab,ti OR ‘evidence based medicine’/exp OR “systematic review”:ab,ti OR “meta-analysis”:ab,ti OR “meta-analyses”:ab,ti NOT (‘case report’/exp OR ‘case study’/exp OR ‘editorial’/exp OR ‘letter’/exp OR ‘note’/exp)
#5 | #1 AND (#2 OR #3) AND #4
#6 | #5, Limits: Humans, English, 2000-present
#7 | #6 AND [embase]/lim NOT [medline]/lim

KQ 5— What are the comparative safety and effectiveness of newer procedural rhythm-control therapies, other nonpharmacological rhythm-control therapies, and pharmacological agents for maintenance of sinus rhythm in atrial fibrillation patients? Do the comparative safety and effectiveness of these therapies differ among specific patient subgroups of interest?

Set # | Terms
#1 | ‘heart atrium fibrillation’/exp OR ‘heart atrium flutter’/exp OR ‘atrial fibrillation’:ab,ti OR (atrial:ab,ti AND fibrillation:ab,ti) OR afib:ab,ti OR ‘atrial flutter’:ab,ti
#2 | ‘catheter ablation’/exp OR ‘cardiac resynchronization therapy’/exp OR non-pharmacological:ab,ti OR nonpharmacological:ab,ti OR ablation:ab,ti OR “surgical maze”:ab,ti OR (surgical:ab,ti AND maze:ab,ti) OR resynchroni*:ab,ti OR (ganglionic:ab,ti AND ablation:ab,ti) OR (ganglionated:ab,ti AND ablation:ab,ti) OR denervation:ab,ti OR “pulmonary vein isolation”:ab,ti OR (pulmonary:ab,ti AND isolation:ab,ti) OR ‘heart stimulation’/exp OR electrical:ab,ti OR cardioversion:ab,ti
#3 | ‘antiarrhythmic agent’/exp OR ((antiarrhythmic:ab,ti OR antiarrhythmia:ab,ti) AND (agent:ab,ti OR agents:ab,ti OR drug:ab,ti OR drugs:ab,ti)) OR ‘flecainide’/exp OR flecainide:ab,ti OR ‘propafenone’/exp OR propafenone:ab,ti OR ‘amiodarone’/exp OR amiodarone:ab,ti OR ‘sotalol’/exp OR sotalol:ab,ti OR ‘ibutilide’/exp OR ibutilide:ab,ti OR ‘dofetilide’/exp OR dofetilide:ab,ti OR ‘dronedarone’/exp OR dronedarone:ab,ti OR ‘disopyramide’/exp OR Disopyramide:ab,ti
#4 | rhythm:ab,ti
#5 | ‘randomized controlled trial’/exp OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random*:ab,ti OR factorial*:ab,ti OR crossover*:ab,ti OR (cross NEAR/1 over*):ab,ti OR placebo*:ab,ti OR (doubl* NEAR/1 blind*):ab,ti OR (singl* NEAR/1 blind*):ab,ti OR assign*:ab,ti OR allocat*:ab,ti OR volunteer*:ab,ti OR ‘clinical study’/exp OR “clinical trial”:ti,ab OR “clinical trials”:ti,ab OR ‘evaluation’/exp OR “evaluation study”:ab,ti OR “evaluation studies”:ab,ti OR “intervention study”:ab,ti OR “intervention studies”:ab,ti OR “case control”:ab,ti OR ‘cohort analysis’/exp OR cohort:ab,ti OR longitudinal*:ab,ti OR prospective:ab,ti OR prospectively:ab,ti OR retrospective:ab,ti OR ‘follow up’/exp OR “follow up”:ab,ti OR ‘comparative effectiveness’/exp OR ‘comparative study’/exp OR “comparative study”:ab,ti OR “comparative studies”:ab,ti OR ‘evidence based medicine’/exp OR “systematic review”:ab,ti OR “meta-analysis”:ab,ti OR “meta-analyses”:ab,ti NOT (‘case report’/exp OR ‘case study’/exp OR ‘editorial’/exp OR ‘letter’/exp OR ‘note’/exp)
#6 | #1 AND (#2 OR #3) AND #4 AND #5
#7 | #6, Limits: Humans, English, 2000-present
#8 | #7 AND [embase]/lim NOT [medline]/lim

KQ 6—What are the comparative safety and effectiveness of rate-control therapies versus rhythm-control therapies in patients with atrial fibrillation? Do the comparative safety and effectiveness of these therapies differ among specific patient subgroups of interest?

Set # | Terms
#1 | ‘heart atrium fibrillation’/exp OR ‘heart atrium flutter’/exp OR ‘atrial fibrillation’:ab,ti OR (atrial:ab,ti AND fibrillation:ab,ti) OR afib:ab,ti OR ‘atrial flutter’:ab,ti
#2 | ((nonpharmacological:ab,ti OR non-pharmacological:ab,ti OR ‘artificial heart pacemaker’/exp OR pacemaker:ab,ti OR (cardiac:ab,ti AND (pace:ab,ti OR pacing:ab,ti) AND artificial:ab,ti) OR ‘heart pacing’/exp OR ‘heart atrioventricular node’/exp OR AVN:ab,ti OR ((atrioventricular:ab,ti OR atrio-ventricular:ab,ti) AND (nodal:ab,ti OR node:ab,ti)) OR ‘catheter ablation’/exp OR “catheter ablation”:ab,ti OR ‘antiarrhythmic agent’/exp OR ((antiarrhythmic:ab,ti OR antiarrhythmia:ab,ti) AND (agent:ab,ti OR agents:ab,ti OR drug:ab,ti OR drugs:ab,ti))) AND (‘heart rate’/exp OR rate:ab,ti)) OR ‘metoprolol’/exp OR metoprolol:ab,ti OR ‘atenolol’/exp OR atenolol:ab,ti OR ‘carvedilol’/exp OR carvedilol:ab,ti OR ‘bisoprolol’/exp OR bisoprolol:ab,ti OR ‘timolol’/exp OR timolol:ab,ti OR ‘esmolol’/exp OR esmolol:ab,ti OR ‘nebivolol’/exp OR nebivolol:ab,ti OR verapamil:ab,ti OR ‘verapamil’/exp OR ‘diltiazem’/exp OR diltiazem:ab,ti OR ‘digoxin’/exp OR ‘acetyldigoxin’/exp OR ‘alpha acetyldigoxin’/exp OR ‘metildigoxin’/exp OR digoxin:ab,ti OR ‘beta adrenergic receptor blocking agent’/exp OR beta-blocker:ab,ti OR beta-blockers:ab,ti OR ‘calcium channel blocking agent’/exp OR ‘acebutolol’/exp OR acebutolol:ab,ti OR ‘nadolol’/exp OR Nadolol:ab,ti
#3 | (‘catheter ablation’/exp OR ‘cardiac resynchronization therapy’/exp OR non-pharmacological:ab,ti OR nonpharmacological:ab,ti OR ablation:ab,ti OR “surgical maze”:ab,ti OR (surgical:ab,ti AND maze:ab,ti) OR resynchroni*:ab,ti OR (ganglionic:ab,ti AND ablation:ab,ti) OR (ganglionated:ab,ti AND ablation:ab,ti) OR denervation:ab,ti OR “pulmonary vein isolation”:ab,ti OR (pulmonary:ab,ti AND isolation:ab,ti) OR ‘cardioversion’/exp OR ‘defibrillation’/exp OR electrical:ab,ti OR cardioversion:ab,ti OR ‘antiarrhythmic agent’/exp OR ((antiarrhythmic:ab,ti OR antiarrhythmia:ab,ti) AND (agent:ab,ti OR agents:ab,ti OR drug:ab,ti OR drugs:ab,ti)) AND rhythm:ab,ti) OR ‘flecainide’/exp OR flecainide:ab,ti OR ‘propafenone’/exp OR propafenone:ab,ti OR ‘amiodarone’/exp OR amiodarone:ab,ti OR ‘sotalol’/exp OR sotalol:ab,ti OR ‘ibutilide’/exp OR ibutilide:ab,ti OR ‘dofetilide’/exp OR dofetilide:ab,ti OR ‘dronedarone’/exp OR dronedarone:ab,ti OR ‘disopyramide’/exp OR Disopyramide:ab,ti
#4 | ‘randomized controlled trial’/exp OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random*:ab,ti OR factorial*:ab,ti OR crossover*:ab,ti OR (cross NEAR/1 over*):ab,ti OR placebo*:ab,ti OR (doubl* NEAR/1 blind*):ab,ti OR (singl* NEAR/1 blind*):ab,ti OR assign*:ab,ti OR allocat*:ab,ti OR volunteer*:ab,ti OR ‘clinical study’/exp OR “clinical trial”:ti,ab OR “clinical trials”:ti,ab OR ‘evaluation’/exp OR “evaluation study”:ab,ti OR “evaluation studies”:ab,ti OR “intervention study”:ab,ti OR “intervention studies”:ab,ti OR “case control”:ab,ti OR ‘cohort analysis’/exp OR cohort:ab,ti OR longitudinal*:ab,ti OR prospective:ab,ti OR prospectively:ab,ti OR retrospective:ab,ti OR ‘follow up’/exp OR “follow up”:ab,ti OR ‘comparative effectiveness’/exp OR ‘comparative study’/exp OR “comparative study”:ab,ti OR “comparative studies”:ab,ti OR ‘evidence based medicine’/exp OR “systematic review”:ab,ti OR “meta-analysis”:ab,ti OR “meta-analyses”:ab,ti NOT (‘case report’/exp OR ‘case study’/exp OR ‘editorial’/exp OR ‘letter’/exp OR ‘note’/exp)
#5 | #1 AND #2 AND #3 AND #4
#6 | #5, Limits: English, Humans, 2000-present
#7 | #6 AND [embase]/lim NOT [medline]/lim

Eliminated KQ^*^—What are the comparative diagnostic accuracy, diagnostic thinking, therapeutic, and patient outcome efficacy of echocardiographic studies and other clinical parameters for predicting successful conversion, successful ablation, successful maintenance of sinus rhythm, and improved outcomes in patients with atrial fibrillation?

Set # | Terms
#1 | ‘heart atrium fibrillation’/exp OR ‘heart atrium flutter’/exp OR ‘atrial fibrillation’:ab,ti OR (atrial:ab,ti AND fibrillation:ab,ti) OR afib:ab,ti OR ‘atrial flutter’:ab,ti
#2 | predictors:ab,ti OR predict:ab,ti OR predicting:ab,ti OR predicts:ab,ti OR predicted:ab,ti OR prognosis:ab,ti OR prognostic:ab,ti OR ‘prognosis’/exp OR accurately:ab,ti OR accuracy:ab,ti OR accurate:ab,ti OR reliability:ab,ti OR sensitivity:ab,ti OR specificity:ab,ti OR ‘sensitivity and specificity’/exp OR ‘treatment outcome’/exp OR ‘diagnosis’/exp OR diagnostic:ab,ti
#3 | maintain:ab,ti OR maintenance:ab,ti OR maintained:ab,ti OR success:ab,ti OR successful:ab,ti OR conversion:ab,ti OR restoration:ab,ti OR restored:ab,ti
#4 | ‘randomized controlled trial’/exp OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random*:ab,ti OR factorial*:ab,ti OR crossover*:ab,ti OR (cross NEAR/1 over*):ab,ti OR placebo*:ab,ti OR (doubl* NEAR/1 blind*):ab,ti OR (singl* NEAR/1 blind*):ab,ti OR assign*:ab,ti OR allocat*:ab,ti OR volunteer*:ab,ti OR ‘clinical study’/exp OR “clinical trial”:ti,ab OR “clinical trials”:ti,ab OR ‘evaluation’/exp OR “evaluation study”:ab,ti OR “evaluation studies”:ab,ti OR “intervention study”:ab,ti OR “intervention studies”:ab,ti OR “case control”:ab,ti OR ‘cohort analysis’/exp OR cohort:ab,ti OR longitudinal*:ab,ti OR prospective:ab,ti OR prospectively:ab,ti OR retrospective:ab,ti OR ‘follow up’/exp OR “follow up”:ab,ti OR ‘comparative effectiveness’/exp OR ‘comparative study’/exp OR “comparative study”:ab,ti OR “comparative studies”:ab,ti OR ‘evidence based medicine’/exp OR “systematic review”:ab,ti OR “meta-analysis”:ab,ti OR “meta-analyses”:ab,ti NOT (‘case report’/exp OR ‘case study’/exp OR ‘editorial’/exp OR ‘letter’/exp OR ‘note’/exp)
#5 | #1 AND #2 AND #3 AND #4
#6 | #5, Limits: English, Humans, 2000-present
#7 | #6 AND [embase]/lim NOT [medline]/lim

## Cochrane Search Strategy (Final Search Date August 1, 2012)

Platform: Wiley

Database searched: Cochrane Database of Systematic Reviews

KQ 1—What are the comparative safety and effectiveness of pharmacological agents used for ventricular rate control in patients with atrial fibrillation? Do the comparative safety and effectiveness of these therapies differ among specific patient subgroups of interest?

Set # | Terms
#1 | MeSH descriptor Atrial Fibrillation explode all trees OR MeSH descriptor Atrial Flutter explode all trees OR “atrial fibrillation”:ab,ti OR (atrial:ab,ti AND fibrillation:ab,ti) OR afib:ab,ti OR “atrial flutter”:ab,ti
#2 | MeSH descriptor Anti-Arrhythmia Agents explode all trees OR MeSH descriptor Adrenergic beta-Antagonists explode all trees OR MeSH descriptor Calcium Channel Blockers explode all trees OR ((antiarrhythmic:ab,ti OR antiarrhythmia:ab,ti) AND (agent:ab,ti OR agents:ab,ti OR drug:ab,ti OR drugs:ab,ti)) OR metoprolol:ab,ti,kw OR atenolol:ab,ti,kw OR carvedilol:ab,ti,kw OR bisoprolol:ab,ti,kw OR timolol:ab,ti,kw OR esmolol:ab,ti,kw OR nebivolol:ab,ti,kw OR verapamil:ab,ti,kw OR diltiazem:ab,ti,kw OR digoxin:ab,ti,kw OR beta-blocker:ab,ti OR beta-blockers:ab,ti OR Acebutolol:ab,ti,kw OR Nadolol:ab,ti,kw OR Amiodarone:ab,ti,kw OR dronedarone:ab,ti,kw
#3 | #1 AND #2
#4 | #3, Limits: Cochrane Reviews, 2000-2012

KQ 2—What are the comparative safety and effectiveness of a strict rate-control strategy versus a more lenient rate-control strategy in patients with atrial fibrillation? Do the comparative safety and effectiveness of these therapies differ among specific patient subgroups of interest?

Set # | Terms
#1 | MeSH descriptor Atrial Fibrillation explode all trees OR MeSH descriptor Atrial Flutter explode all trees OR “atrial fibrillation”:ab,ti OR (atrial:ab,ti AND fibrillation:ab,ti) OR afib:ab,ti OR “atrial flutter”:ab,ti
#2 | ((rate:ab,ti OR heart rate:ab,ti,kw) AND control:ab,ti) AND (strategy:ab,ti OR lenient:ab,ti OR strict:ab,ti)
#3 | #1 AND #2
#4 | #3, Limits: Cochrane Reviews, 2000-2012

KQ 3—What are the comparative safety and effectiveness of newer procedural and other nonpharmacological rate-control therapies compared with pharmacological agents in patients with atrial fibrillation who have failed initial pharmacotherapy? Do the comparative safety and effectiveness of these therapies differ among specific patient subgroups of interest?

Set # | Terms
#1 | MeSH descriptor Atrial Fibrillation explode all trees OR MeSH descriptor Atrial Flutter explode all trees OR “atrial fibrillation”:ab,ti OR (atrial:ab,ti AND fibrillation:ab,ti) OR afib:ab,ti OR “atrial flutter”:ab,ti
#2 | MeSH descriptor Pacemaker, Artificial explode all trees OR MeSH descriptor Cardiac Pacing, Artificial explode all trees OR MeSH descriptor Atrioventricular Node explode all trees OR MeSH descriptor Catheter Ablation explode all trees OR nonpharmacological:ab,ti OR non-pharmacological:ab,ti OR pacemaker:ab,ti OR (cardiac:ab,ti AND (pace:ab,ti OR pacing:ab,ti) AND artificial:ab,ti) OR AVN:ab,ti OR ((atrioventricular:ab,ti OR atrio-ventricular:ab,ti) AND (nodal:ab,ti OR node:ab,ti)) OR “catheter ablation”:ab,ti
#3 | rate:ab,ti OR heart rate:ab,ti,kw
#4 | #1 AND #2 AND #3
#5 | #4, Limits: Cochrane Reviews, 2000-2012

KQ 4—What are the comparative safety and effectiveness of available antiarrhythmic agents and electrical cardioversion for conversion of atrial fibrillation to sinus rhythm? Do the comparative safety and effectiveness of these therapies differ among specific patient subgroups of interest?

Set # | Terms
#1 | MeSH descriptor Atrial Fibrillation explode all trees OR MeSH descriptor Atrial Flutter explode all trees OR “atrial fibrillation”:ab,ti OR (atrial:ab,ti AND fibrillation:ab,ti) OR afib:ab,ti OR “atrial flutter”:ab,ti
#2 | MeSH descriptor Anti-Arrhythmia Agents explode all trees OR ((antiarrhythmic:ab,ti OR antiarrhythmia:ab,ti) AND (agent:ab,ti OR agents:ab,ti OR drug:ab,ti OR drugs:ab,ti)) OR flecainide:ab,ti,kw OR propafenone:ab,ti,kw OR amiodarone:ab,ti,kw OR sotalol:ab,ti,kw OR ibutilide:ab,ti,kw OR dofetilide:ab,ti,kw OR dronedarone:ab,ti,kw OR Disopyramide:ab,ti,kw
#3 | MeSH descriptor Electric Countershock explode all trees OR electrical:ab,ti OR cardioversion:ab,ti
#4 | #1 AND (#2 OR #3)
#5 | #4, Limits: Cochrane Reviews, 2000-2012

KQ 5—What are the comparative safety and effectiveness of newer procedural rhythm-control therapies, other nonpharmacological rhythm-control therapies, and pharmacological agents for maintenance of sinus rhythm in atrial fibrillation patients? Do the comparative safety and effectiveness of these therapies differ among specific patient subgroups of interest?

Set # | Terms
#1 | MeSH descriptor Atrial Fibrillation explode all trees OR MeSH descriptor Atrial Flutter explode all trees OR “atrial fibrillation”:ab,ti OR (atrial:ab,ti AND fibrillation:ab,ti) OR afib:ab,ti OR “atrial flutter”:ab,ti
#2 | MeSH descriptor Catheter Ablation explode all trees OR MeSH descriptor Cardiac Resynchronization Therapy explode all trees OR MeSH descriptor Electric Countershock explode all trees OR non-pharmacological:ab,ti OR nonpharmacological:ab,ti OR ablation:ab,ti OR “surgical maze”:ab,ti OR (surgical:ab,ti AND maze:ab,ti) OR resynchroni*:ab,ti OR (ganglionic:ab,ti AND ablation:ab,ti) OR (ganglionated:ab,ti AND ablation:ab,ti) OR denervation:ab,ti OR “pulmonary vein isolation”:ab,ti OR (pulmonary:ab,ti AND isolation:ab,ti) OR electrical:ab,ti OR cardioversion:ab,ti
#3 | MeSH descriptor Anti-Arrhythmia Agents explode all trees OR ((antiarrhythmic:ab,ti OR antiarrhythmia:ab,ti) AND (agent:ab,ti OR agents:ab,ti OR drug:ab,ti OR drugs:ab,ti)) OR flecainide:ab,ti,kw OR propafenone:ab,ti,kw OR amiodarone:ab,ti,kw OR sotalol:ab,ti,kw OR ibutilide:ab,ti,kw OR dofetilide:ab,ti,kw OR dronedarone:ab,ti,kw OR Disopyramide:ab,ti,kw
#4 | rhythm:ab,ti
#5 | #1 AND (#2 OR #3) AND #4
#6 | #5, Limits: Cochrane Reviews, 2000-2012

KQ 6—What are the comparative safety and effectiveness of rate-control therapies versus rhythm-control therapies in patients with atrial fibrillation? Do the comparative safety and effectiveness of these therapies differ among specific patient subgroups of interest?

Set # | Terms
#1 | MeSH descriptor Atrial Fibrillation explode all trees OR MeSH descriptor Atrial Flutter explode all trees OR “atrial fibrillation”:ab,ti OR (atrial:ab,ti AND fibrillation:ab,ti) OR afib:ab,ti OR “atrial flutter”:ab,ti
#2 | MeSH descriptor Pacemaker, Artificial explode all trees OR MeSH descriptor Cardiac Pacing, Artificial explode all trees OR MeSH descriptor Atrioventricular Node explode all trees OR MeSH descriptor Catheter Ablation explode all trees OR MeSH descriptor Anti-Arrhythmia Agents explode all trees OR MeSH descriptor Adrenergic beta-Antagonists explode all trees OR MeSH descriptor Calcium Channel Blockers explode all trees OR ((nonpharmacological:ab,ti OR non-pharmacological:ab,ti OR pacemaker:ab,ti OR (cardiac:ab,ti AND (pace:ab,ti OR pacing:ab,ti) AND artificial:ab,ti)) OR AVN:ab,ti OR ((atrioventricular:ab,ti OR atrio-ventricular:ab,ti) AND (nodal:ab,ti OR node:ab,ti)) OR “catheter ablation”:ab,ti OR ((antiarrhythmic:ab,ti OR antiarrhythmia:ab,ti) AND (agent:ab,ti OR agents:ab,ti OR drug:ab,ti OR drugs:ab,ti) AND (heart rate:ab,ti,kw OR rate:ab,ti)) OR metoprolol:ab,ti,kw OR atenolol:ab,ti,kw OR carvedilol:ab,ti,kw OR bisoprolol:ab,ti,kw OR timolol:ab,ti,kw OR esmolol:ab,ti,kw OR nebivolol:ab,ti,kw OR verapamil:ab,ti,kw OR diltiazem:ab,ti,kw OR digoxin:ab,ti,kw OR OR beta-blocker:ab,ti OR beta-blockers:ab,ti OR Acebutolol:ab,ti,kw OR Nadolol:ab,ti,kw
#3 | MeSH descriptor Catheter Ablation explode all trees OR MeSH descriptor Cardiac Resynchronization Therapy explode all trees OR MeSH descriptor Electric Countershock explode all trees OR MeSH descriptor Anti-Arrhythmia Agents explode all trees OR non-pharmacological:ab,ti OR nonpharmacological:ab,ti OR ablation:ab,ti OR “surgical maze”:ab,ti OR (surgical:ab,ti AND maze:ab,ti) OR resynchroni*:ab,ti OR (ganglionic:ab,ti AND ablation:ab,ti) OR (ganglionated:ab,ti AND ablation:ab,ti) OR denervation:ab,ti OR “pulmonary vein isolation”:ab,ti OR (pulmonary:ab,ti AND isolation:ab,ti) OR electrical:ab,ti OR cardioversion:ab,ti OR ((antiarrhythmic:ab,ti OR antiarrhythmia:ab,ti) AND (agent:ab,ti OR agents:ab,ti OR drug:ab,ti OR drugs:ab,ti)) AND rhythm:ab,ti) OR flecainide:ab,ti,kw OR propafenone:ab,ti,kw OR amiodarone:ab,ti,kw OR sotalol:ab,ti,kw OR ibutilide:ab,ti,kw OR dofetilide:ab,ti,kw OR dronedarone:ab,ti,kw OR Disopyramide:ab,ti,kw
#4 | #1 AND #2 AND #3
#5 | #4, Limits: Cochrane Reviews, 2000-2012

Eliminated KQ^*^—What are the comparative diagnostic accuracy, diagnostic thinking, therapeutic, and patient outcome efficacy of echocardiographic studies and other clinical parameters for predicting successful conversion, successful ablation, successful maintenance of sinus rhythm, and improved outcomes in patients with atrial fibrillation?

Set # | Terms
#1 | MeSH descriptor Atrial Fibrillation explode all trees OR MeSH descriptor Atrial Flutter explode all trees OR “atrial fibrillation”:ab,ti OR (atrial:ab,ti AND fibrillation:ab,ti) OR afib:ab,ti OR “atrial flutter”:ab,ti
#2 | MeSH descriptor Prognosis explode all trees OR MeSH descriptor Sensitivity and Specificity explode all trees OR MeSH descriptor Treatment Outcome explode all trees OR MeSH descriptor Diagnosis explode all trees OR predictors:ab,ti OR predict:ab,ti OR predicting:ab,ti OR predicts:ab,ti OR predicted:ab,ti OR prognosis:ab,ti OR prognostic:ab,ti OR accurately:ab,ti OR accuracy:ab,ti OR accurate:ab,ti OR reliability:ab,ti OR sensitivity:ab,ti OR specificity:ab,ti OR diagnostic:ab,ti
#3 | maintain:ab,ti OR maintenance:ab,ti OR maintained:ab,ti OR success:ab,ti OR successful:ab,ti OR conversion:ab,ti OR restoration:ab,ti OR restored:ab,ti
#4 | #1 AND #2 and #3
#5 | #4, Limits: Cochrane Reviews, 2000-2011

## Grey Literature Searches

### ClinicalTrials.gov (Final Search Date August 17, 2012)

Condition | atrial fibrillation OR afib OR atrial flutter
Intervention | Drug OR device OR procedure

Total number of results: 610

### WHO: International Clinical Trials Registry Platform Search Portal (Final Search Date August 17, 2012)

Terms: atrial fibrillation OR afib OR atrial flutter

Total number of results: 858

### ProQuest COS Conference Papers Index (Final Search Date August 1, 2012)

S1 | All (atrial fibrillation OR afib OR atrial flutter)
S2 | nonpharmacological OR non-pharmacological OR pacemaker OR (cardiac AND (pace OR pacing) AND artificial) OR AVN OR ((atrioventricular OR atrio-ventricular) AND (nodal OR node)) OR “catheter ablation” OR ((antiarrhythmic OR antiarrhythmia) AND (agent OR agents OR drug OR drugs)) OR metoprolol OR atenolol OR carvedilol OR bisoprolol OR timolol OR esmolol OR nebivolol OR verapamil OR diltiazem OR digoxin OR “Adrenergic beta-Antagonists” OR beta-blocker OR beta-blockers OR “Calcium Channel Blockers” OR Acebutolol OR Nadolol OR “Catheter Ablation” OR “Cardiac Resynchronization Therapy” OR non-pharmacological OR nonpharmacological OR ablation OR (surgical AND maze) OR resynchroni* OR (ganglionic AND ablation) OR (ganglionated AND ablation) OR denervation OR (pulmonary AND isolation) OR “electric countershock” OR electrical OR cardioversion OR flecainide OR propafenone OR propafenone OR amiodarone OR sotalol OR ibutilide OR dofetilide OR dronedarone OR Disopyramide OR (rate AND control AND (strict OR lenient OR strategy))
S3 | S1 AND S2

Total number of results: 1747