# Abbreviations

AAD: antiarrhythmic drug
ACC: American College of Cardiology
ACCF: American College of Cardiology Foundation
AF: atrial fibrillation
AFFIRM: Atrial Fibrillation Follow-Up Investigation of Rhythm Management
AHA: American Heart Association
AHRQ: Agency for Healthcare Research and Quality
AIRCRAFT: Australian Intervention Randomized Control of Rate in Atrial Fibrillation Trial
AVN: atrioventricular node
bpm: beats per minute
CABANA: Catheter Ablation versus Antiarrhythmic Drug Therapy for Atrial Fibrillation trial
CAD: coronary artery disease
CARE-HF: Cardiac REsynchronization in Heart Failure
CDSR: Cochrane Database of Systematic Reviews
CER: comparative effectiveness review
CFAE: complex fractionated atrial electrogram
CRT: cardiac resynchronization therapy
CTI: cavotricuspid isthmus
CV: cardiovascular
DDDR: dual chamber demand rate-responsive
ECG: electrocardiogram
ESC: European Society of Cardiology
FDA: U.S. Food and Drug Administration
HR: hazard ratio
HRS: Heart Rhythm Society
ICD: implantable cardioverter defibrillator;
ICTRP: International Clinical Trials Registry Platform
IOM: Institute of Medicine
IQR: interquartile range
J: Joules
KQ(s): Key Question(s)
LVEF: left ventricular ejection fraction
LVH: left ventricular hypertrophy
MI: myocardial infarction
NR: not reported
NS: not statistically significant
NYHA: New York Heart Association
PICOTS: Populations, Interventions, Comparators, Outcomes, Timings, and Settings of interest
PRISMA: Preferred Reporting Items for Systematic Reviews and Meta-Analyses
PV: pulmonary vein
PVI: pulmonary vein isolation
RACE(-II): Rate Control Efficacy in Permanent Atrial Fibrillation(-II)
RCT(s): randomized controlled trial(s)
RFA: radiofrequency ablation
RV: right ventricular
SD: standard deviation
SF-36: Medical Outcomes Study 36-Item Short Form Health Survey
TEP: Technical Expert Panel
VVIR: ventricular demand rate-responsive
WHO: World Health Organization