# Results

In this chapter, we describe the results of our literature searches followed by detailed results organized by KQ. For each KQ, we list the key points of the findings and provide a brief description of the included studies, followed by a detailed synthesis of the evidence. Across all KQs we present any relevant subgroup or harms data. (Tables C-1, C-2, and C-3 in Appendix C provide details and quality ratings for the included studies by population and comparison for each KQ.) We conducted quantitative syntheses where possible, as described in the Methods chapter. A list of abbreviations and acronyms used in this chapter is provided at the end of the report.

## Results of Literature Searches

In Figure 3, we depict the flow of articles through the literature search and screening process for the review. Searches of PubMed,^®^ Embase,^®^ and the Cochrane Database of Systematic Reviews from January 1995 to August 2012 yielded 5908 citations, 1082 of which were duplicates. Manual searching and contacts to drug manufacturers identified 47 additional citations, for a total of 4873. After applying inclusion/exclusion criteria at the title-and-abstract level, 626 full-text articles were retrieved and screened. Of these, 521 were excluded at the full-text screening stage, leaving 105 articles (representing 83 unique studies) for data abstraction. Appendix D provides a detailed listing of included articles. Appendix E provides a complete list of articles excluded at the full-text screening stage, with reasons for exclusion.

Figure 3 Literature flow diagram

Abbreviations: KQ=Key Question; RCT=randomized controlled trial.

This figure shows the flow of articles through the literature search and screening process. Searches of PubMed®, Embase®, and the Cochrane Database of Systematic Reviews from January 1995 to August 2012 yielded 5908 citations, 1082 of which were duplicates. Manual searching and contacts to drug manufacturers identified 47 additional citations, for a total of 4873. After applying inclusion/exclusion criteria at the title-and-abstract level, 626 full-text articles were retrieved and screened. Of these, 521 were excluded at the full-text screening stage, leaving 105 articles (representing 83 unique studies) for data abstraction. 14 articles (representing 11 studies of which 10 were RCTs and 1 was observational) were applicable to KQ 1; 44 articles (representing 35 studies of which 27 were RCTs and 8 were observational) were applicable to KQ 2; and 47 articles (representing 37 studies of which 3 were RCTs and 34 were observational) were applicable to KQ 3.

As described in the Methods chapter, we searched ClinicalTrials.gov to identify completed but unpublished studies as a mechanism for ascertaining publication bias. Our search yielded 436 study records, 240 of which were completed at least 1 year prior to our search of the database and review of the published literature. A single reviewer identified 16 of these records as potentially relevant. We identified and screened publications for all 16 study records. Since we did not find any relevant study records without publications, we do not believe that there is significant publication bias in the evidence base that would impact our overall findings.

## KQ 1 Comparative Effectiveness and Safety of Antiplatelet Therapy in Adults With PAD

KQ 1. In adults with peripheral artery disease (PAD), including asymptomatic patients and symptomatic patients with atypical leg symptoms, intermittent claudication (IC), or critical limb ischemia (CLI):

a. What is the comparative effectiveness of aspirin and other antiplatelet agents in reducing the risk of adverse cardiovascular events (e.g., all-cause mortality, myocardial infarction, stroke, cardiovascular death), functional capacity, and quality of life?
b. Does the effectiveness of treatments vary according to the patient's PAD classification or by subgroup (age, sex, race, risk factors, or comorbidities)?
c. What are the significant safety concerns associated with each treatment strategy (e.g., adverse drug reactions, bleeding)? Do the safety concerns vary by subgroup (age, sex, race, risk factors, comorbidities, or PAD classification)?

### Key Points

#### Effectiveness of Interventions

- For asymptomatic PAD patients, there appears to be no benefit of aspirin over placebo for all-cause mortality, cardiovascular mortality, MI, or stroke (high SOE for all outcomes except cardiovascular mortality, which was rated moderate based on two good-quality RCTs).
- For IC patients, one small fair-quality RCT suggests with low SOE that aspirin compared with placebo may reduce MI (fatal and nonfatal) and composite vascular events (MI/stroke/pulmonary embolus), but there was insufficient SOE for all other outcomes due to study quality and imprecision.
- For IC patients, the PAD subgroup analysis of the CAPRIE RCT suggests that clopidogrel is more effective than aspirin for reducing cardiovascular mortality, nonfatal MI, and composite vascular events (moderate SOE for all outcomes). Clopidogrel and aspirin appear to be equivalent for prevention of nonfatal stroke, but the confidence interval was wide, making this conclusion less certain (low SOE).
- In patients with symptomatic or asymptomatic PAD, the PAD subgroup analysis of the CHARISMA RCT showed no difference between aspirin and dual therapy (clopidogrel plus aspirin) for outcomes of all-cause mortality (moderate SOE), nonfatal stroke (low SOE), cardiovascular mortality (low SOE), or composite vascular events (moderate SOE). There was a statistically significant benefit favoring dual therapy compared with aspirin for reducing nonfatal MI (low SOE).
- In patients with IC or CLI after unilateral bypass, the CASPAR RCT showed that DAPT resulted in no difference in nonfatal stroke and composite vascular events (low SOE), but there was insufficient SOE for other outcomes.
- In patients with IC or CLI after endovascular procedure, the MIRROR RCT showed no difference between dual therapy and aspirin in cardiovascular events or mortality at 6 months but was insufficiently powered for those outcomes (insufficient SOE).

#### Modifiers of Effectiveness

- Four RCTs reported subgroup analyses of demographic or clinical factors that modify the effect of antiplatelet agents in PAD and involved 5053 patients. Two of these RCTs included asymptomatic or high-risk patients and two included patients with either IC or CLI. Subgroups analyzed included diabetes (one RCT), age (one RCT), sex (two RCTs), and PAD characteristics (two RCTs assessing ABI or type of bypass graft). The small number of and variation in subgroup analyses precluded the calculation of any overall estimate.
- One RCT of patients with IC or CLI showed a benefit of clopidogrel plus aspirin for reducing composite vascular events in patients with a prosthetic bypass graft compared with those with a venous bypass graft. Clinical outcomes were similar in men and women treated with antiplatelet agents. Given the heterogeneity of the subgroups, interventions, and clinical outcomes, the SOE for modifiers of effectiveness was insufficient.

#### Safety Concerns

- Seven RCTs reported safety concerns from antiplatelet treatment in the PAD population and involved 8297 patients. All seven RCTs reported bleeding as a harm. In general, use of antiplatelet agents was associated with higher rates of minor and moderate bleeding compared with placebo, ranging from 2 to 4 percent with aspirin, 2 percent with dual antiplatelet (no procedure), and 2.5 to 16.7 percent with dual antiplatelet (after percutaneous transluminal angioplasty or bypass grafting). Some RCTs reported adverse events such as rash and wound leak. The SOE for safety concerns is insufficient.

### Description of Included Studies

We identified 11 unique studies (10 RCTs, 1 observational) that evaluated the comparative effectiveness of aspirin and antiplatelet agents in 15,150 patients with PAD.54-64 Of these studies, seven were rated good quality, three fair, and one poor. (Characteristics for each study are presented in Table C-1 in Appendix C.) The following comparisons were assessed in the included studies and are detailed in this analysis:

1. Aspirin versus placebo or no antiplatelet (3 RCTs, 1 observational study)54-57
2. Clopidogrel/aspirin comparisons: clopidogrel with aspirin (dual antiplatelet) versus aspirin (4 RCTs)60,61,63,64 and clopidogrel versus aspirin (1 RCT)59
3. Other antiplatelet comparisons: aspirin or iloprost versus no antiplatelet (1 RCT)62 and high-dose aspirin versus low-dose aspirin (1 RCT)58

### Detailed Synthesis

#### Effectiveness of Interventions

##### 1 Aspirin Versus Placebo or No Antiplatelet

Two studies (both RCTs and rated good quality) compared aspirin with placebo, with no aspirin, or with no antiplatelet agent in asymptomatic patients.54,56 These studies involved 3986 patients. One RCT (rated fair quality) compared aspirin with placebo in 181 patients with IC.55 One observational study (retrospective cohort, rated poor quality) compared aspirin with no aspirin in 113 patients with CLI.57 Sample sizes for individual studies ranged from 113 to 3350 patients. Study durations ranged from 2 to 10 years.

The mean age of study participants ranged from 60 to 72 years of age. The proportion of female patients ranged from 22 to 72 percent. None of the studies reported the racial and ethnic demographics of study participants. Few studies reported functional status or quality of life. Few studies reported the use of concomitant medications such as aspirin, antihypertensive medications, and HMG-CoA reductase medications.

All studies were conducted in Europe. Funding source was reported in three studies (75%), with two studies funded by a combination of government and industry funding54,56 and one study funded by industry.55

Table 7 summarizes the clinical outcomes reported by the authors for each study as well as the calculated hazard ratio used in the meta-analyses. Meta-analyses of the hazard ratios were performed using Comprehensive Meta-Analysis Version 2.0.

Table 7 Calculated hazard ratios for aspirin versus placebo or no antiplatelet

Study Population | Type of Study N Analyzed^a^ Comparison Quality | Length of Followup | Results Reported by Authors | Calculated HR (95% CI)^b^
Belch, 2008^54^ POPADAD Study Patients with diabetes mellitus and asymptomatic PAD | RCT N: 636 ASA vs. placebo Good | 6.7 yr | Nonfatal MI: ASA 34, no ASA 28 Nonfatal stroke: ASA 11, no ASA 22 CV mortality: ASA 20, no ASA 11 Composite vascular events: ASA 58, no ASA 57 | Nonfatal MI: 0.98 (0.68 to 1.42) Nonfatal stroke: 0.71 (0.44 to 1.14) CV mortality: 1.23 (0.79 to 1.92) Composite vascular events: 0.98 (0.76 to 1.26)
Catalano, 2007^55^ CLIPS Study Patients with IC | RCT N: 181 ASA vs. placebo Fair | 2 yr | Nonfatal MI: ASA 0, placebo 2 Nonfatal stroke: ASA 0, placebo 5 CV mortality: ASA 2, placebo 3 Composite vascular events: ASA 1, placebo 10 | Nonfatal MI: 0.18 (0.04 to 0.82) Nonfatal stroke: 0.54 (0.16 to 1.84) CV mortality: 1.21 (0.32 to 4.55) Composite vascular events: 0.35 (0.15 to 0.82)
Fowkes, 2010^56^ Patients with asymptomatic PAD and no previous cardiovascular disease | RCT N: 3350 ASA vs. placebo Good | 10 yr | Nonfatal MI: ASA 3.7%, placebo 4.1% Nonfatal stroke: ASA 0.4%, placebo 0.7% CV mortality: ASA 1.7%, placebo 1.1% Composite vascular events: ASA 10.8%, placebo 10.5% | Nonfatal MI: 0.91 (0.65 to 1.29) Nonfatal stroke: 0.97 (0.59 to 1.12) CV mortality: 0.95 (0.77 to 1.7) Composite vascular events: 1.00 (0.85 to 1.17)
Mahmood, 2003^57^ Patients with CLI after infrainguinal bypass surgery | Retrospective cohort N: 113 ASA vs. no ASA Poor | 2 yr | Nonfatal MI: ASA 1, no ASA 2 Nonfatal stroke: ASA 2, no ASA 3 CV mortality: ASA 26, no ASA 9 Composite vascular events: none reported | Nonfatal MI: ASA 1.2%, no ASA 5.9% Nonfatal stroke: ASA 2.5%, no ASA 8.8% CV mortality: ASA 33%, no ASA 26%

a Number of patients in the study arms of interest.

b Applies to studies used in the meta-analysis.

Abbreviations: ASA=acetylsalicylic acid (aspirin); CI=confidence interval; CV=cardiovascular; HR=hazard ratio; MI=myocardial infarction; RCT=randomized controlled trial; yr=year/years.

###### Effect on All-Cause Mortality

Two good-quality RCTs reported an all-cause mortality outcome in asymptomatic patients.54,56 In the POPADAD study,54 the total mortality rate was 11.9 percent in the aspirin group and 13.2 percent in the placebo group after a median followup time of 6.7 years. In the Fowkes study,56 the total mortality rate was 12.8 percent in the aspirin group and 13.5 percent in the placebo group after 10 years (HR 0.95; 95% CI, 0.77 to 1.16). Results in both studies were not statistically significant. Given the consistent results from two good-quality RCTs on a direct outcome, the SOE was rated as high.

###### Effect on Nonfatal MI

Four studies reported nonfatal MI outcomes.54-57 Three of these studies were RCTs and reported a nonfatal MI outcome in patients with PAD who were either asymptomatic or symptomatic without a recent procedure54-56 with a median duration of 6.7 years. The fourth study57 was excluded because of cohort study design (retrospective cohort) and patient population (postbypass patients with CLI).

Figure 4 shows the forest plot of the hazard ratios for the three RCTs that reported nonfatal MI events. Aspirin compared with placebo had no statistically significant effect on nonfatal MI. The confidence interval for the study by Catalano et al.55 is wider since it is a smaller study, and the hazard ratio strongly favored aspirin and is likely due to the symptomatic (IC) population. The observational study57 reported one nonfatal MI (1.2%) in the aspirin treatment arm and two nonfatal MIs (5.9%) in the no-aspirin treatment arm 2 years after infrainguinal bypass for CLI. The overall SOE was rated high for the asymptomatic population and low for the IC-CLI population and insufficient for the CLI population.

Figure 4 Forest plot for RCTs of aspirin versus placebo: nonfatal MI at 2 or more years

Abbreviations: CI=confidence interval; IC=intermittent claudication; PAD=peripheral artery disease.

This figure shows the forest plot of the hazard ratio for the three RCTs that reported nonfatal MI events. The Belch, 2008 (POPADAD) study and the Fowkes, 2010 study both looked at asymptomatic PAD patients and had total Ns of 636 and 3350 respectively. The Catalano, 2007 (CLIPS) study looked at IC patients and had a total N of 181. The result was an estimated hazard ratio of 0.98 (95% CI, 0.68 to 1.42, p=0.92) favoring aspirin for the Belch study. The estimated hazard ratio for the Fowkes study was 0.91 (CI, 0.65 to 1.29, p=0.60) favoring aspirin. The estimated hazard ratio for the Catalano study was 0.18 (CI, 0.04 to 0.82, p=0.03) favoring aspirin.

###### Effect on Nonfatal Stroke

Four studies reported nonfatal stroke outcomes.54-57 Three of these were RCTs and reported a stroke outcome in patients with PAD who were either asymptomatic or symptomatic without a recent procedure54-56 with a median duration of 6.7 years. The fourth study57 was a retrospective cohort study of patients with CLI receiving infrainguinal bypass surgery and was excluded because of study design and patient population.

Figure 5 shows the forest plot of the hazard ratios for the three RCTs that reported nonfatal stroke events. Aspirin compared with placebo had no statistically significant effect on nonfatal stroke. The summary estimate for Catalano et al. has a wider confidence interval since it is a smaller study and the hazard ratio appears to favor aspirin more than the Belch and Fowkes studies which is likely due to the symptomatic (IC) population, which can be assumed to have a higher degree of stenosis and CAD burden compared with the asymptomatic population. The findings from the Catalano study are inconclusive given the wide CI that crosses 1. The observational study57 reported two strokes (2.5%) in patients receiving aspirin and three strokes (8.8%) in patients not receiving aspirin 2 years after infrainguinal bypass for CLI. The overall SOE was rated high for the asymptomatic population and insufficient for the IC-CLI and CLI populations.

Figure 5 Forest plot for RCTs of aspirin versus placebo: nonfatal stroke at 2 or more years

Abbreviations: CI=confidence interval; IC=intermittent claudication; PAD=peripheral artery disease.

This figure shows the forest plot of the hazard ratio for the three RCTs that reported nonfatal MI events. The Belch, 2008 (POPADAD) study and the Fowkes, 2010 study both looked at asymptomatic PAD patients and had total Ns of 636 and 3350 respectively. The Catalano, 2007 (CLIPS) study looked at IC patients and had a total N of 181. The result was an estimated hazard ratio of 0.71 (95% CI, 0.44 to 1.14, p=0.16) favoring aspirin for the Belch study. The estimated hazard ratio for the Fowkes study was 0.97 (CI, 0.62 to 1.53, p=0.91) favoring aspirin. The estimated hazard ratio for the Catalano study was 0.54 (CI, 0.16 to 1.84, p=0.32) favoring aspirin.

###### Effect on Cardiovascular Mortality

Four studies reported cardiovascular mortality outcomes.54-57 Three of these were RCTs and reported a cardiovascular mortality outcome in patients with PAD who were either asymptomatic or symptomatic without a recent procedure.54-56 The fourth study57 was a retrospective cohort study of patients with CLI receiving infrainguinal bypass surgery. Of the 79 patients in the treatment arm of that study, 47 received aspirin preoperatively and 32 received aspirin postoperatively; the comparison group (n=34) received no aspirin. Given the differences in study design (observational study) and patient population (postsurgical), this study was not included in the meta-analysis.

Figure 6 shows the forest plot of the hazard ratios for the three RCTs that reported cardiovascular mortality events. Aspirin compared with placebo had no statistically significant effect on cardiovascular mortality in either the asymptomatic PAD patients or the IC population. The observational study,57 which was rated poor quality, reported a rate of vascular death in 33 percent of patients receiving aspirin and 26 percent in patients not receiving aspirin after 2 years after infrainguinal bypass for CLI (p=0.67). The overall SOE was rated moderate for the asymptomatic population and insufficient for the IC-CLI and CLI populations.

Figure 6 Forest plot for RCTs of aspirin versus placebo: cardiovascular mortality at 2 or more years

Abbreviations: Asym=asymptomatic; CI=confidence interval; IC=intermittent claudication; PAD=peripheral artery disease.

This figure shows the forest plot of the hazard ratio for the three RCTs that reported nonfatal MI events. The Belch, 2008 (POPADAD) study and the Fowkes, 2010 study both looked at asymptomatic PAD patients and had total Ns of 636 and 3350 respectively. The Catalano, 2007 (CLIPS) study looked at IC patients and had a total N of 181. The result was an estimated hazard ratio of 1.23 (95% CI, 0.79 to 1.92, p=0.36) favoring aspirin for the Belch study. The estimated hazard ratio for the Fowkes study was 0.95 (CI, 0.77 to 1.17, p=0.62) favoring aspirin. The estimated hazard ratio for the Catalano study was 1.21 (CI, 0.32 to 4.55, p=0.78) favoring aspirin.

###### Effect on Composite Vascular Events

Three RCTs reported a composite of vascular event outcomes; namely, cardiovascular death, nonfatal stroke, and nonfatal MI in patients with PAD who were either asymptomatic or symptomatic at a median duration of 6.7 years.54-56 Figure 7 shows the forest plot of the hazard ratios for these three RCTs. Similar to the analyses on the individual outcomes (cardiovascular mortality, nonfatal stroke, and nonfatal MI), aspirin compared with placebo had no statistically significant effect on vascular events. Again, the confidence interval for the study by Catalano et al.55 is wider since it is a smaller study, and the hazard ratio strongly favored aspirin and is likely due to the symptomatic (IC) population. The overall SOE was rated high for the asymptomatic population and low for the IC population.

Figure 7 Forest plot for RCTs of aspirin versus placebo: composite vascular events at 2 or more years

Abbreviations: Asym=asymptomatic; CI=confidence interval; IC=intermittent claudication; PAD=peripheral artery disease.

This figure shows the forest plot of the hazard ratio for the three RCTs that reported nonfatal MI events. The Belch, 2008 (POPADAD) study and the Fowkes, 2010 study both looked at asymptomatic PAD patients and had total Ns of 636 and 3350 respectively. The Catalano, 2007 (CLIPS) study looked at IC patients and had a total N of 181. The result was an estimated hazard ratio of 0.98 (95% CI, 0.76 to 1.26, p=0.88) favoring aspirin for the Belch study. The estimated hazard ratio for the Fowkes study was 1.00 (CI, 0.85 to 1.17, p=1.00) favoring aspirin. The estimated hazard ratio for the Catalano study was 0.35 (CI, 0.15 to 0.82, p=0.02) favoring aspirin.

###### Effect on Other Outcomes

None of the studies comparing aspirin with placebo, with no aspirin, or with no antiplatelet drug reported functional outcomes such as MWD, PWT, or COT. The effect of aspirin on quality of life also was not reported. Therefore, SOE for the effect of aspirin on functional outcomes and quality of life is insufficient.

##### 2 Clopidogrel/Aspirin Comparisons

###### Clopidogrel With or Without Aspirin Versus Aspirin Monotherapy

One good-quality RCT59 compared clopidogrel monotherapy with aspirin monotherapy in a PAD subpopulation within a larger study of high-risk vascular populations (prior MI, cerebrovascular accident, PAD). This RCT was conducted internationally and involved 6452 PAD patients with a mean duration of follow up of 1.9 years.

Four studies (all RCTS and rated good quality) compared clopidogrel plus aspirin with aspirin monotherapy in patients with asymptomatic PAD (one RCT), IC (one RCT), and a mixed population of either IC or CLI (two RCTs) (Table 8).60,61,63-65 These RCTs involved 4130 patients. Sample sizes for individual studies ranged from 80 to 3096 patients. Study durations ranged from 30 days to 28 months. Three RCTs were conducted internationally,60,63-65 and one RCT was conducted at a single site in the United Kingdom.61

Table 8 Calculated hazard ratio for clopidogrel with or without aspirin versus placebo with aspirin

Study Population | Type of Study N Analyzed^a^ Comparison Quality | Length of Followup | Results Reported by Authors | Calculated HR (95% CI)^b^
Clopidogrel monotherapy vs. aspirin monotherapy
Anonymous, 1996^59^ CAPRIE Study Patients with IC or history of endovascular or bypass surgery | RCT N: 6452 Clopidogrel vs. ASA Good | 2 yr | Nonfatal MI: Clopidogrel 50, ASA 81 Nonfatal stroke: Clopidogrel 70, ASA 74 CV mortality: Clopidogrel 66, ASA 87 Composite vascular events: Clopidogrel 215, ASA 277 | Nonfatal MI: 0.62 (0.43 to 0.88) Nonfatal stroke: 0.95 (0.68 to 1.31) CV mortality: 0.76 (0.64 to 0.91) Composite vascular events: 0.78 (0.65 to 0.93)
Clopidogrel plus aspirin (dual antiplatelet) vs. aspirin monotherapy
Belch, 2010^63^ CASPAR Study Patients with IC or CLI status post unilateral bypass graft | RCT N: 851 Clopidogrel/ASA vs. ASA Good | 2 yr | Nonfatal MI: HR 0.81 (0.32 to 2.06) Nonfatal stroke: HR 1.02 (0.41 to 2.57) CV mortality: HR 1.44 (0.77 to 2.68) Composite vascular events: HR 1.09 (0.65 to 1.82) Note: Actual event rates not reported | Nonfatal MI: 0.81 (0.32 to 2.06) Nonfatal stroke: 1.02 (0.41 to 2.56) CV mortality: 1.44 (0.77 to 2.69) Composite vascular events: 1.09 (0.65 to 1.82)
Cacoub, 2009^60^ Bhatt, 2007^65^ CHARISMA Study Patients with PAD (92% symptomatic [IC], 8% asymptomatic) | RCT N: 3096 Clopidogrel/ASA vs. ASA Good | 28 mo | Nonfatal MI: Clopidogrel/ASA 2.3%, ASA 3.7% Nonfatal stroke: Clopidogrel/ASA 2.3%, ASA 3.0% CV mortality: Clopidogrel/ASA 4.2% ASA. 4.6% Composite vascular events: Clopidogrel 7.6%, ASA 8.9% | Nonfatal MI: 0.63 (0.42 to 0.96) Nonfatal stroke: 0.79 (0.0.51 to 1.21) CV mortality: 0.92 (0.65 to 1.28) Composite vascular events: 0.85 (0.66 to 1.08)
Cassar, 2005^61^ Patients with IC | RCT N: 103 Clopidogrel/ASA vs. ASA Good | 30 days | Only reports adverse drug reactions and platelet reactivity | Not estimated
Tepe, 2012^64^ MIRROR Study Patients with IC or CLI status post endovascular procedure | RCT N: 80 Clopidogrel/ASA vs. ASA Good | 6 mo | Mortality: Clopidogrel 0%, ASA 2.5% Composite vascular events: Clopidogrel 30%, ASA 37.5% | Mortality: OR 0.33 (0.01 to 8.22) Composite vascular events: OR 0.71 (0.28 to 1.81)

a Number of patients in the study arms of interest.

b Applies to studies used in the meta-analysis.

Abbreviations: ASA=acetylsalicylic acid (aspirin); CI=confidence interval; CLI=critical limb ischemia; CV=cardiovascular; HR=hazard ratio; IC=intermittent claudication; MI=myocardial infarction; mo=month/months; OR=odds ratio; RCT=randomized controlled trial; yr=year/years.

The mean age of study participants ranged from 64 to 70 years of age. The proportion of female patients ranged from 22 to 48 percent. None of the RCTs reported the racial and ethnic demographics of study participants. Few RCTs reported functional status or quality of life. Few RCTs reported the use of concomitant medications such as aspirin, antihypertensive medications, and HMG-CoA reductase medications. Industry funded the four international RCTs, and a mixture of nonprofit and industry funding sources was reported for the single-site study.61

###### Clopidogrel Monotherapy Versus Aspirin Monotherapy

In the PAD subgroup of the CAPRIE RCT,59 there was a statistically significant benefit of clopidogrel monotherapy over aspirin monotherapy, hazard ratio 0.76 (95% CI, 0.64 to 0.91, p=0.003), in regard to cardiovascular mortality. The overall SOE is moderate given the results of one large RCT on a direct outcome and narrow confidence interval. There was no difference in the rates of nonfatal stroke hazard ratio 0.95 (CI, 0.68 to 1.31, p=0.74). The overall SOE is low given the results of one large RCT on a direct outcome and wide confidence interval. CAPRIE also showed a statistically significant reduction in the rate of nonfatal MI, hazard ratio 0.62 (CI, 0.43 to 0.88, p=0.01). The overall SOE is moderate given the results of one large RCT on a direct outcome and narrow confidence interval. For composite vascular events (cardiovascular mortality, nonfatal stroke, and nonfatal MI), there was a statistically significant reduction, hazard ratio 0.78 (CI, 0.65 to 0.93, p=0.01). The overall SOE is moderate given the results of one large RCT on a direct outcome and narrow confidence interval. Overall, there is moderate evidence that clopidogrel monotherapy is superior to aspirin monotherapy in the reduction of cardiovascular mortality, nonfatal MI, and composite vascular events but low evidence that it affects nonfatal stroke in the PAD population (Figure 8). This study did not evaluate outcomes for all-cause mortality, functional outcomes, quality of life, modifiers of effectiveness, or safety concerns.

Figure 8 Clopidogrel versus aspirin for all outcomes in PAD subgroup of CAPRIE RCT

Abbreviations: CI=confidence interval; CV=cardiovascular; MI-myocardial infarction.

This figure displays a forest plot of all outcomes in the CAPRIE study. The result was an estimated hazard ratio for CV mortality of 0.76 (95% CI, 0.64 to 0.91, p=0.00) favoring clopidogrel. The estimated hazard ratio for nonfatal stroke was 0.95 (95% CI 0.68 to 1.31, p=0.74) favoring clopidogrel. The estimated hazard ratio for nonfatal MI was 0.62 (CI, 0.43 to 0.88, p=0.01) favoring clopidogrel. The estimated hazard ratio for composite CV events was 0.78 (CI, 0.65 to 0.93, p=0.01) favoring clopidogrel.

###### Clopidogrel Plus Aspirin (Dual Antiplatelet) Versus Aspirin Monotherapy

Four RCTs compared clopidogrel plus aspirin (DAPT) with aspirin monotherapy. The CHARISMA RCT60 reported results for the PAD subpopulation (92% IC, 8% asymptomatic) within a larger study of high-risk vascular populations (prior MI, cerebrovascular accidents, and PAD). The CASPAR RCT63 assessed a PAD population (33% IC, 67% CLI) who received unilateral below-the-knee (infrageniculate) bypass surgery. The MIRROR RCT64 assessed a PAD population (66% IC, 44% CLI) that underwent percutaneous transluminal angioplasty. The RCT by Cassar et al.61 reported adverse drug outcomes up to 30 days after an endovascular procedure for IC (see Safety Concerns section); the main finding was greater platelet function inhibition with dual therapy.

###### Effect on All-Cause Mortality

Three good-quality RCTs reported an all-cause mortality outcome.60,63,64 In the CHARISMA RCT,60 the all-cause mortality hazard ratio was 0.89 (0.68 to 1.16) in the clopidogrel plus aspirin group compared with the aspirin group after 28 months of followup. In the CASPAR RCT,63 the all-cause mortality hazard ratio was 1.44 (95% CI, 0.77 to 2.69) in the clopidogrel plus aspirin group compared with the aspirin group after a followup time of 2 years. In the MIRROR RCT,64 the all-cause mortality odds ratio was 0.33 (CI, 0.01 to 8.22) in the clopidogrel plus aspirin group compared with the aspirin group after a followup time of 6 months. In all three RCTs, the results were not statistically significant. Differences in these results among the RCTs may be due to the patient population (IC-asymptomatic vs. IC-CLI). The overall SOE was rated moderate for the IC-asymptomatic population and insufficient for the IC-CLI populations.

###### Effect on Nonfatal MI

Two RCTs reported nonfatal MI outcomes with a median duration of treatment of 2 years.60,63,65 Clopidogrel plus aspirin reduced the rate of nonfatal MI compared with aspirin alone which was statistically significant in the CHARISMA RCT, hazard ratio 0.63 (95% CI, 0.42 to 0.95, p=0.03) and nonsignificant in the CASPAR RCT, hazard ratio 0.81 (CI, 0.32 to 2.06, p=0.66). The overall SOE was rated low for the IC-Asymptomatic population and insufficient for the IC-CLI postbypass population.

###### Effect on Nonfatal Stroke

Two RCTs reported nonfatal stroke outcomes with a median duration of 2 years.60,63,65 The CHARISMA RCT showed a nonsignificant benefit of DAPT over aspirin monotherapy, hazard ratio 0.79 (95% CI, 0.51 to 1.22, p=0.28), but the CASPAR RCT showed no significant difference, hazard ratio 1.02 (CI, 0.41 to 2.55, p=0.97). The overall SOE was rated low for both the IC-Asymptomatic population and the IC-CLI postbypass population.

###### Effect on Cardiovascular Mortality

Two RCTs reported cardiovascular mortality outcomes with a median duration of 2 years.60,63,65 In these RCTs (CHARISMA and CASPAR), DAPT had a no significant difference in the CHARISMA PAD subgroup, hazard ratio 0.92 (95% CI, 0.66 to 1.29, p=0.63), and was inconclusive in the CASPAR postbypass surgery population, hazard ratio 1.44 (CI, 0.77 to 2.69, p=0.25). The overall SOE was rated low for the IC-Asymptomatic population and insufficient for the IC-CLI postbypass population.

###### Effect on Composite Vascular Events

Three RCTs reported composite vascular event outcomes; namely, cardiovascular mortality, nonfatal stroke, and nonfatal MI, at around 6 months64 or 2 years of followup.60,63,65 Clopidogrel plus aspirin did not impact the rate of composite vascular events compared with aspirin alone: CHARISMA RCT, hazard ratio 0.85 (0.66 to 1.09, p=0.20), CASPAR RCT, hazard ratio 1.09 (0.65 to 1.82, p=0.74) and MIRROR RCT, OR 0.71 (0.28 to 1.81, p=0.48). The overall SOE was rated moderate for the IC-Asymptomatic population, low for the IC-CLI postbypass population and insufficient for the IC-CLI post percutaneous transluminal angioplasty population.

###### Effect on Other Outcomes

None of the RCTs comparing clopidogrel plus aspirin to aspirin reported functional outcomes such as MWD, ACD, PWT, or COT. The effect of clopidogrel plus aspirin on quality of life also was not reported. Therefore SOE for the effect of clopidogrel plus aspirin on functional outcomes and quality of life is insufficient. Figure 9 shows the hazard ratios for each outcome measured in the CHARISMA and CASPAR RCT. Figure 10 shows the odds ratios for each outcome measured in the MIRROR RCT.

Figure 9 Dual antiplatelet versus aspirin outcomes in CHARISMA and CASPAR RCTs

Abbreviations: Asym=asymptomatic; CI=confidence interval; CLI=critical limb ischemia; CV=cardiovascular; IC=intermittent claudication; MI-myocardial infarction.

This figure shows the forest plot for this random-effects meta-analysis for dual antiplatelet versus aspirin outcomes in the CHARISMA and CASPAR studies. The result is an estimated hazard ratio of 0.89 (95% CI, 0.68 to 1.16, p=0.39) favoring dual antiplatelet therapy for all death in the CHARISMA study. The estimated hazard ratio for the composite outcome in the CHARISMA study is 0.85 (CI, 0.66 to 1.09, p=0.20) favoring dual antiplatelet therapy. The estimated hazard ratio for CV death in the CHARISMA study is 0.92 (CI, 0.66 to 1.29, p=0.63) favoring dual antiplatelet therapy. The estimated hazard ratio for MI in the CHARISMA study is 0.63 (CI, 0.42 to 0.95, p=0.03) favoring dual antiplatelet therapy. The estimated hazard ratio for stroke in the CHARISMA study is 0.79 (CI, 0.51 to 1.22, p=0.28) favoring dual antiplatelet therapy. The estimated hazard ratio for all death in the CASPAR study is 1.44 (CI, 0.77 to 2.69, p=0.25) favoring aspirin. The estimated hazard ratio for the composite outcome in the CASPAR study is 1.09 (CI 0.65 to 1.82, p=0.74) favoring aspirin. The estimated hazard ratio for CV death in the CASPAR study is 1.44 (CI, 0.77 to 2.69, p=0.25) favoring aspirin. The estimated hazard ratio for MI in the CASPAR study is 0.81 (CI, 0.32 to 2.06, p=0.66) favoring dual antiplatelet therapy. The estimated hazard ratio for stroke in the CASPAR study is 1.02 (CI, 0.41 to 2.55, p=0.97) favoring aspirin.

Figure 10 Dual antiplatelet versus aspirin outcomes in MIRROR RCT

Abbreviations: CI=confidence interval.

This figure displays a forest plot of outcomes in the MIRROR study. The result was an estimated odds ratio for all death of 0.33 (95% CI, 0.01 to 8.22, p=0.50) favoring dual antiplatelet. The estimated odds ratio for the composite outcome was 0.71 (CI, 0.28 to 1.81, p=0.48) favoring dual antiplatelet.

##### 3 Other Antiplatelet Comparisons

Two studies (both RCTs and rated fair quality) assessed other antiplatelet comparisons in patients with IC or CLI.58,62 The RCTs involved 254 patients and compared (1) aspirin or iloprost versus no antiplatelet agent in patients with IC or CLI after percutaneous transluminal angioplasty (PTA)62 and (2) aspirin 1000 mg versus aspirin 100 mg in patients with IC or CLI after femoropopliteal PTA.58 The smaller RCT included 38 patients while the larger RCT included 216 patients. Mean study duration was 1.5 years. The mean age of study participants was 66 to 68 years of age. The proportion of female patients ranged from 32 to 42 percent. Neither study reported the use of concomitant medications such as aspirin, antihypertensive medications, and HMG-CoA reductase medications. Both studies were conducted in Europe and neither reported funding source.

Results for various clinical outcomes are shown in Table 9. Due to the small number of studies and significant heterogeneity in the comparators, outcomes, and timing, a quantitative analysis was not possible. Neither RCT reported a composite outcome. Both RCTs assessed postprocedural outcomes and reported rates of vessel patency/restenosis/reocclusion. One RCT reported total mortality.58 Neither RCT reported functional outcomes or quality of life. In both RCTs there were no significant differences found between the treatment groups for all outcomes measured.

Table 9 Results of other antiplatelet comparisons

Study | Type of Study N Analyzed^a^ Comparison Quality | Outcome Length of Followup | Results Reported by Authors
Horrocks, 1997^62^ Patients with IC or CLI | RCT (open label) N: 38 ASA or iloprost vs. no antiplatelet Fair | Restenosis Reocclusion 3 mo | Restenosis: ASA 5, iloprost 0, placebo 3 Reocclusion: ASA 0, iloprost 1, placebo 0
Minar, 1995^58^ Patients with IC or CLI | RCT N: 216 ASA 1000 mg vs. ASA 100 mg Fair | Total mortality Primary vessel patency 2 yr | Total mortality: 1000 mg ASA 14; 100 mg ASA 13 Primary vessel patency: 1000 mg ASA 62.5% 100 mg ASA 62.6%

a Number of patients in the study arms of interest.

Abbreviations: ASA=acetylsalicylic acid (aspirin); CLI=critical limb ischemia; IC=intermittent claudication; LSM=least squares mean; mg=milligram; RCT=randomized controlled trial; yr=year/years.

#### Modifiers of Effectiveness

Four RCTs (three good quality, one fair) reported variations in treatment effectiveness by subgroup (Table 10).54,56,58,63 Two RCTs compared aspirin with placebo in asymptomatic or high-risk patients,54,56 one RCT compared 1000 mg of aspirin with 100 mg of aspirin in patients with IC or CLI,58 and one RCT compared clopidogrel plus aspirin with aspirin alone in patients with IC or CLI undergoing unilateral below the knee bypass.63

Table 10 Studies reporting subgroup results of antiplatelet therapy (modifiers of effectiveness)

Study Population | Type of Study N Analyzed^a^ Comparison Quality | Subgroup | Results Reported by Authors
Belch, 2008^54^ POPADAD Study Patients with diabetes mellitus and asymptomatic PAD | RCT N: 636 ASA vs. placebo Good | Diabetes | CV mortality: 21 ASA, 14 placebo Stroke: 0 ASA, 5 placebo
Belch, 2010^63^ CASPAR Study Patients with IC or CLI | RCT N: 851 Clopidogrel/ASA vs. ASA Good | Type of bypass graft venous vs. prosthetic | Composite CV events: Venous: HR 1.25 (0.94 to 1.67) Prosthetic: HR 0.65 (0.45 to 0.95) Significant reduction in prosthetic graft patients receiving DAPT, but not in venous graft patients
Fowkes, 2010^56^ Patients with asymptomatic PAD and no previous cardiovascular disease | RCT N: 3350 ASA vs. placebo Good | Age <62 yr vs. ≥62 yr Sex ABI ≤0.95, ≤0.90, ≤0.85, ≤0.80 | Composite CV events: <62: HR 0.85 (0.65 to 1.20) ≥ 62: HR 1.13 (0.97 to 1.47) Composite CV events: Men: HR 1.15 (0.86 to 1.54) Women: HR 0.92 (0.68 to 1.23) Composite CV events: ≤0.95: HR 1.03 (0.84 to 1.27) ≤0.90: HR 1.02 (0.80 to 1.29) ≤0.85: HR 0.99 (0.73 to 1.35) ≤0.80: HR 1.06 (0.73 to 1.54)
Minar, 1995^58^ Patients with IC or CLI | RCT N: 216 ASA 1000 mg vs. ASA 100 mg Fair | Sex | Vessel patency: Aspirin dosage had no influence on the cumulative patency in either sex

a Number of patients in the study arms of interest.

Abbreviations: ABI=ankle brachial index; ASA=acetylsalicylic acid (aspirin); CLI=critical limb ischemia; CV=cardiovascular; HR=hazard ratio; IC=intermittent claudication; RCT=randomized controlled trial.

Subgroups analyzed included diabetes (one study54), age (one RCT56), sex (two RCT56,58), type of bypass graft (one RCT63), and ABI (one RCT56). One RCT63 showed a benefit of clopidogrel plus aspirin for reducing composite vascular events in patients with a prosthetic bypass graft compared to those with a venous bypass graft. Clinical outcomes were similar in men and women treated with antiplatelet agents. We found no studies reporting subgroup results by race or risk factors (e.g., tobacco use, presence of hyperlipidemia). Given the heterogeneity of the subgroups, interventions, and clinical outcomes, the SOE for modifiers of effectiveness was insufficient.

#### Safety Concerns

Seven RCTs (six good quality, one fair) reported safety concerns associated with each treatment strategy (Table 11).54-56,60,61,63,64 All seven RCTs reported bleeding, GI bleeding, or anemia as a harm: three RCTs comparing aspirin with placebo in asymptomatic patients54,55 or patients with IC56 and four RCTs comparing clopidogrel plus aspirin with aspirin alone in high-risk asymptomatic patients,60 patients with IC,61 and in a mixed population of patients with either IC or CLI.63,64 A quantitative analysis of bleeding rates was not possible due to the low number of studies by treatment comparison, variation in the bleeding definition, and differences in measurement time points. In two aspirin versus placebo RCTs, the rates of major hemorrhage or bleeding were slightly higher in the aspirin groups; a third RCT showed lower rates of gastrointestinal bleeding in the aspirin group. In the dual antiplatelet groups, bleeding rates ranged from 2 to 3 percent (with one study showing a rate of 28 percent in the immediate postoperative period) compared with bleeding rates ranging from 0 to 6 percent in the placebo groups. There was no significant difference in bleeding except in the immediate postoperative period.

Table 11 Studies reporting harms of antiplatelet therapy

Study Population | Type of Study N Analyzed^a^ Comparison Quality | Harm Length of Followup | Results Reported by Authors
Belch, 2008^54^ POPADAD Study Patients with diabetes mellitus and asymptomatic PAD | RCT N: 636 ASA vs. placebo Good | 1. GI bleed; 2. GI symptoms; 3. Arrhythmia; 4. Rash; 6.7 yr | 1. GI bleed: ASA 13 (4%), placebo 18 (6%); 2. GI symptoms: ASA 40 (13%), placebo 58 (18%); 3. Arrhythmia: ASA 27 (9%), placebo 25 (8%); 4. Rash: ASA 38 (12%), placebo 30 (9%)
Belch, 2010^63^ CASPAR Study Patients with IC or CLI status post unilateral bypass graft | RCT N: 851 Clopidogrel/ASA vs. ASA Good | Bleeding 2 yr | Bleeding: clopidogrel 71 (16.7%), placebo 30 (7.1%), p=0.001 Severe bleeding: clopidogrel 9 (2.1%); placebo 5 (1.2%), P=NS Moderate bleeding: clopidogrel 16 (3.8%); placebo 4 (0.9%), p=0.007 Mild bleeding: clopidogrel 46 (10.8%); placebo 21 (5%), p=0.002
Cacoub, 2009^60^ CHARISMA Study PAD subgroup (92% CI, 8% asymptomatic) | RCT N: 3096 Clopidogrel/ASA vs. ASA Good | Bleeding 28 mo | Severe bleed: clopidogrel/ASA 1.7%, ASA 1.7%, p=0.90 Moderate bleed: clopidogrel/ASA 2.5%, ASA 1.9%, p=0.26 Minor bleed: clopidogrel/ASA 34.4%, ASA 20.8%, p<0.001
Cassar, 2005^61^ Patients with IC status post-PTA | RCT N: 103 Clopidogrel/ASA vs. ASA Good | 1. GI Bleed; 2. Rash; 3. Hematoma; 4. Bruising; 30 days | 1. GI bleed: clopidogrel/ASA 1, ASA 0; 2. Rash: clopidogrel/ASA 2, ASA 2; 3. Hematoma: clopidogrel/ASA 2 peripheral and 1 retroperitoneal, ASA 2; 4. Bruising: clopidogrel/ASA 25, ASA 16
Catalano, 2007^55^ CLIPS Study Patients with IC | RCT N: 181 ASA vs. placebo Fair | Bleeding 2 yr | ASA 3%, placebo 0%
Fowkes, 2010^56^ Patients with asymptomatic PAD and no previous cardiovascular disease | RCT N: 3350 ASA vs. placebo Good | 1. Major hemorrhage; 2. GI ulcer; 3. Retinal hemorrhage; 4. Severe anemia; 10 yr | 1. Major hemorrhage: ASA 2.0%, placebo 1.2%; 2. GI ulcer: ASA 0.8%, placebo 0.5%; 3. Retinal hemorrhage: ASA 0.1%, placebo 0.2%; 4. Severe anemia: ASA 25, placebo 16
Tepe, 2012^64^ MIRROR study Patients with IC or CLI status post percutaneous transluminal angioplasty | RCT N: 80 Clopidogrel/ASA vs. ASA Good | Bleeding 6 mo | Bleeding: clopidogrel 1 (2.5%), placebo 2 (5%), p=0.559

a Number of patients in the study arms of interest.

Abbreviations: ASA=acetylsalicylic acid (aspirin); CI=confidence interval; CLI=critical limb ischemia; CV=cardiovascular; GI=gastrointestinal; HR=hazard ratio; IC=intermittent claudication; mo=month/months; NS=not significant; RCT=randomized controlled trial; SD=standard deviation; wk=week/weeks; yr=year/years.

Two RCTs reported the adverse side effect of a rash (two studies54,61), which was higher in patients receiving aspirin compared with placebo and similar in patients receiving DAPT or aspirin. None of the RCTs reported on whether any harms varied by subgroup (age, sex, race, risk factors, comorbidities, anatomic location of disease). Therefore, the SOE for safety concerns is insufficient.

### SOE Ratings for KQ 1

Tables 12–14 summarize the SOE for the outcomes of cardiovascular mortality, nonfatal stroke, nonfatal MI, and composite vascular events. No studies reported results on functional outcomes or quality of life. Very few studies reported modifiers of effectiveness or safety outcomes.

Table 12 Detailed SOE for aspirin versus placebo in adults with asymptomatic or symptomatic PAD at 2+ years

Population Study Design Number of Studies (Total Patients) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect Effect Estimate (95% CI)
All-cause mortality
Asymptomatic RCT 2 (3986) | 2 low risk | Consistent | Direct | Precise | HR 0.93 (0.71 to 1.24) HR 0.95 (0.77 to 1.16) No difference High SOE
Nonfatal MI
Asymptomatic RCT 2 (3986) | 2 low risk | Consistent | Direct | Precise | HR 0.98 (0.68 to 1.42) HR 0.91 (0.65 to 1.29) No difference High SOE
IC RCT 1 (181) | 1 moderate risk | NA | Direct | Imprecise | HR 0.18 (0.04 to 0.82) Favors aspirin Low SOE
CLI Observational 1 (113) | 1 high risk | NA | Direct | Unknown | No difference between aspirin (1.2%) and no-aspirin (5.9%) groups Insufficient SOE
Nonfatal stroke
Asymptomatic RCT 2 (3986) | 2 low risk | Consistent | Direct | Precise | HR 0.71 (0.44 to 1.14) HR 0.97 (0.62 to 1.53) No difference High SOE
IC RCT 1 (181) | 1 moderate risk | NA | Direct | Imprecise | HR 0.54 (0.16 to 1.84) Inconclusive Insufficient SOE
CLI Observational 1 (113) | 1 high risk | NA | Direct | Unknown | No difference between aspirin (2.5%) and no-aspirin (8.8%) groups Insufficient SOE
Cardiovascular mortality
Asymptomatic RCT 2 (3986) | 2 low risk | Consistent | Direct | Imprecise | HR 1.23 (0.79 to 1.92) HR 0.95 (0.77 to 1.17) No difference Moderate SOE
IC RCT 1 (181) | 1 moderate risk | NA | Direct | Imprecise | HR 1.21 (0.32 to 4.55) Inconclusive Insufficient SOE
CLI Observational 1 (113) | 1 high risk | NA | Direct | Unknown | No difference between aspirin (33%) and no-aspirin (26%) groups Insufficient SOE
Composite vascular events
Asymptomatic RCT 2 (3986) | 2 low risk | Consistent | Direct | Precise | HR 0.98 (0.76 to 1.26) HR 1.00 (0.85 to 1.17) No difference High SOE
IC RCT 1 (181) | 1 moderate risk | NA | Direct | Imprecise | HR 0.35 (0.15 to 0.82) Favors aspirin Low SOE
Modifiers of effectiveness (subgroups)
Asymptomatic IC-CLI RCT 3 (4202) | 2 low risk, 1 moderate risk | NA | NA | NA | No differences in outcomes by age, sex, or baseline ABI in aspirin studies Insufficient SOE
Safety concerns
Asymptomatic or IC RCT 3 (4167) | 2 low risk, 1 moderate risk | NA | NA | NA | Bleeding rates slightly higher in aspirin group (2 to 4%) compared to placebo (0 to 6%) Insufficient SOE
Functional outcomes Quality of life Safety concerns (subgroups)
0 | NA | NA | NA | NA | Insufficient SOE

Abbreviations: ABI=ankle-brachial index; CI=confidence interval; CLI=critical limb ischemia; HR=hazard ratio; IC=intermittent claudication; NA=not applicable; Obs=observational; PTA=percutaneous transluminal angioplasty; RCT=randomized controlled trial; SOE=strength of evidence.

Table 13 Detailed SOE for clopidogrel versus aspirin in adults with IC at 2 years (CAPRIE)

Study Design Number of Studies (Total Patients) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect Effect Estimate (95% CI)
Nonfatal MI
IC RCT 1 (6452) | 1 low risk | NA | Direct | Precise | HR 0.62 (0.43 to 0.88) Favors clopidogrel Moderate SOE
Nonfatal stroke
IC RCT 1 (6452) | 1 low risk | NA | Direct | Imprecise | HR 0.95 (0.68 to 1.31) No difference Low SOE
Cardiovascular mortality
IC RCT 1 (6452) | 1 low risk | NA | Direct | Precise | HR 0.76 (0.64 to 0.91) Favors clopidogrel Moderate SOE
Composite cardiovascular events
IC RCT 1 (6452) | 1 low risk | NA | Direct | Precise | HR 0.78 (0.65 to 0.93) Favors clopidogrel Moderate SOE
All-cause mortality Functional outcomes Quality of life Modifiers of effectiveness (subgroups) Safety concerns Safety concerns (subgroups)
0 | NA | NA | NA | NA | Insufficient SOE

Abbreviations: CI=confidence interval; HR=hazard ratio; NA=not applicable; RCT=randomized controlled trial; SOE=strength of evidence.

Table 14 Detailed SOE for clopidogrel plus aspirin versus aspirin monotherapy in adults with PAD at 2 years

Population Study Design Number of Studies (Total Patients) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect Effect Estimate (95% CI)
All-cause mortality
Symptomatic-asymptomatic RCT 1 (3096) | 1 low risk | NA | Direct | Precise | HR 0.89 (0.68 to 1.16) No difference Moderate SOE
IC-CLI (postbypass) RCT 1 (851) | 1 low risk | NA | Direct | Imprecise | HR 1.44 (0.77 to 2.69) Inconclusive Insufficient SOE
IC-CLI (post-PTA) RCT 1 (80) | 1 low risk | NA | Direct | Imprecise | OR 0.33 (0.01 to 8.22) Inconclusive Insufficient SOE
Nonfatal MI
Symptomatic-asymptomatic RCT 1 (3096) | 1 low risk | NA | Direct | Precise | HR 0.63 (0.42 to 0.95) Favors dual antiplatelet Low SOE
IC-CLI (postbypass) RCT 1 (851) | 1 low risk | NA | Direct | Imprecise | HR 0.81 (0.32 to 2.06) Inconclusive Insufficient SOE
Nonfatal stroke
Symptomatic-asymptomatic RCT 1 (3096) | 1 low risk | NA | Direct | Imprecise | HR 0.79 (0.51 to 1.22) No difference Low SOE
IC-CLI (postbypass) RCT 1 (851) | 1 low risk | NA | Direct | Imprecise | HR 1.02 (0.41 to 2.55) No difference Low SOE
Cardiovascular mortality
Symptomatic-asymptomatic RCT 1(3096) | 1 low risk | NA | Direct | Imprecise | HR 0.92 (0.66 to 1.29) No difference Low SOE
IC-CLI (postbypass) RCT 1 (851) | 1 low risk | NA | Direct | Imprecise | HR 1.44 (0.77 to 2.69) Inconclusive Insufficient SOE
Composite cardiovascular events
Symptomatic-asymptomatic RCT 1 (3096) | 1 low risk | NA | Direct | Precise | HR 0.85 (0.66 to 1.09) No difference Moderate SOE
IC-CLI (postbypass) RCT 1 (851) | 1 low risk | NA | Direct | Imprecise | HR 1.09 (0.65 to 1.82) No difference Low SOE
IC-CLI (post-PTA) RCT 1 (80) | 1 low risk | NA | Direct | Imprecise | OR 0.71 (0.28 to 1.81) Inconclusive Insufficient SOE
Modifiers of effectiveness (subgroups)
IC-CLI (postbypass) RCT 1 (851) | 1 low risk | NA | NA | NA | Patients with prosthetic graft had lower cardiovascular events on DAPT Insufficient SOE
Safety concerns
All RCT 4 (4079) | 4 low risk | NA | NA | NA | CASPAR study showed statistically significant higher rates of moderate and minor bleeding with DAPT; CHARISMA study showed statistically significant higher rate of minor bleeding with DAPT; Cassar study showed more bruising with DAPT but no significant difference in GI bleed or hematoma; MIRROR study showed no significant difference in bleeding Insufficient SOE
Functional outcomes Quality of life Safety concerns (subgroups)
0 | NA | NA | NA | NA | Insufficient SOE

Abbreviations: CI=confidence interval; CLI=critical limb ischemia; DAPT=dual antiplatelet therapy; GI=gastrointestinal; HR=hazard ratio; IC=intermittent claudication; MI=myocardial infarction; NA=not applicable; OR=odds ratio; RCT=randomized controlled trial; SOE=strength of evidence.

## KQ 2 Comparative Effectiveness and Safety of Exercise, Medications, and Endovascular and Surgical Revascularization for IC

KQ 2. In adults with symptomatic PAD (atypical leg symptoms or IC):

a. What is the comparative effectiveness of exercise training, medications (cilostazol, pentoxifylline), endovascular intervention (percutaneous transluminal angioplasty, atherectomy, or stents), and/or surgical revascularization (endarterectomy, bypass surgery) on outcomes including cardiovascular events (e.g., all-cause mortality, myocardial infarction, stroke, cardiovascular death), amputation, quality of life, wound healing, analog pain scale score, functional capacity, repeat revascularization, and vessel patency?
b. Does the effectiveness of treatments vary by use of exercise and medical therapy prior to invasive management or by subgroup (age, sex, race, risk factors, comorbidities, or anatomic location of disease)?
c. What are the significant safety concerns associated with each treatment strategy (e.g., adverse drug reactions, bleeding, contrast nephropathy, radiation, infection, exercise-related harms, and periprocedural complications causing acute limb ischemia)? Do the safety concerns vary by subgroup (age, sex, race, risk factors, comorbidities, anatomic location of disease)?

### Key Points

#### Effectiveness of Interventions

- In a random-effects network meta-analysis of 12 RCTs that assessed the effect of 6 comparisons on all-cause mortality, no specific treatment was found to have a statistically significant effect (low SOE for all comparisons).
- In a random-effects meta-analysis of 16 RCTs that compared the effect of multiple treatments on MWD or ACD, exercise training, pentoxifylline, and the combination of endovascular treatment with exercise were associated with large effects when compared with usual care. Cilostazol and endovascular intervention were associated with moderate effects when compared with usual care. None of the other treatments were found to have a statistically significant effect when compared against each other. A sensitivity analysis removing the pentoxifylline studies (due to inconsistency and imprecision) resulted in effect size estimates that are slightly increased for the remaining treatment modalities. We observed similar results in studies that were excluded due to measurement of peak walking time rather than distance. SOE was rated moderate for exercise; low for cilostazol, endovascular treatment, and the combination of endovascular treatment with exercise; and insufficient for pentoxifylline.
- In a random-effects meta-analysis of 12 RCTs that compared the effect of multiple treatments on ICD or PFWD, cilostazol was associated with a statistically nonsignificant improvement when compared with usual care (effect size 0.63; 95% CI, -0.02 to 1.29, p=0.06); however, exercise training and endovascular revascularization were associated with moderate to large effects and a statistically significant improvement when compared with usual care (effect size 0.69; CI, 0.23 to 1.15, p=0.003; and effect size 0.79; CI, 0.29 to 1.29, p=0.002, respectively). When directly compared in head-to-head studies, there was no difference between the three treatments. Similar results were observed in studies excluded due to measurement of claudication onset time rather than distance. SOE was rated low across all comparisons.
- A random-effects meta-analysis of 10 RCTs examining the difference in the SF-36 measure of physical functioning assessed between 3 months and 6 months showed a significant improvement in quality of life from cilostazol, exercise training, endovascular intervention, and surgical revascularization ranging from moderate to large effects compared with usual care. However, the comparisons of all active treatments with each other showed that none of the treatments are significantly different from each other. SOE was rated low for all comparisons.
- Cardiovascular events (e.g. myocardial infarction, stroke, cardiovascular death), amputation, wound healing, analog pain scale score, repeat revascularization, and vessel patency were infrequently reported. SOE was rated insufficient for all comparisons.
- One observational study of surgical revascularization versus usual care reported mortality and vessel patency results at 5 years. SOE was rated insufficient.

#### Modifiers of Effectiveness

- Four RCTs and two observational studies reported variations in the treatment effectiveness by subgroup including severity of symptoms, functional limitations, anatomic location of disease, and success of revascularization. Despite limited data to draw definitive conclusions, one observational study reported improvements in quality of life measures and ABI in patients with successful endovascular revascularization when compared with patients without successful endovascular revascularization. Another study reported improvement in ABI in patients with successful surgical revascularization when compared with patients treated with exercise and medical therapy. One other RCT reported a statistically nonsignificant improvement in MWD favoring exercise training over endovascular revascularization in patients with superficial femoral artery (SFA) stenosis when compared with patients with iliac stenosis. Last, a single observational study reported variability in the patency of surgical revascularization based on anatomic location and graft type.
- We found no studies reporting results by the following subgroups: age, sex, race, presence of diabetes mellitus or renal disease, smoking status, use of exercise or medical therapy prior to invasive management, or prior revascularization. The SOE for modifiers of effectiveness was insufficient given the variation in subgroups that were studied and the outcomes reported.

#### Safety Concerns

Seventeen RCTs reported safety concerns. A single RCT of exercise therapy versus usual care did not identify side effects from exercise. RCTs of cilostazol had higher rates of headache (OR 3.00; 95% CI, 2.29 to 3.95; high SOE), diarrhea (OR 2.51; CI, 1.58 to 3.97; moderate SOE), and palpitation complications (OR 18.32; CI, 5.95 to 55.13; moderate SOE). RCTs of endovascular interventions reported more transfusions, arterial dissection/perforation, and hematomas compared to the usual care groups but the complication rates were low (1 to 2%). No studies were identified that measured contrast nephropathy, radiation, infection, or exercise-related harms. No studies reported on whether any of the harms vary by subgroup (age, sex, race, risk factors, comorbidities, anatomic location of disease). The SOE for safety concerns by subgroup was insufficient.

### Description of Included Studies

We identified 35 unique studies that evaluated the comparative effectiveness of exercise training, medications, endovascular intervention, and/or surgical revascularization in 7475 patients who have PAD with IC.16,25,49,51,66-96 Of these studies, 27 were RCTs (12 good quality, 13 fair, 2 poor) and 8 were observational (4 fair, 4 poor). (Characteristics for each study are presented in Table C-2 in Appendix C.)

The following comparisons were assessed in the included studies and are detailed in this analysis:

1. Medical therapy (cilostazol or pentoxifylline) versus usual care (10 RCTs; 4103 total patients)25,49,51,73,85-90
2. Exercise training versus usual care (10 RCTs, 2 observational; 754 total patients)66,68-71,73-75,77-79,96
3. Endovascular intervention versus usual care (5 RCTs, 4 observational; 1593 total patients)70,72,74,77,91-95
4. Surgical revascularization versus usual care (1 observational; 427 total patients)76
5. Endovascular intervention versus exercise training (9 RCTs; 1005 total patients)16,70,74,77,80-84
6. Surgical revascularization versus exercise training plus medical therapy (1 observational; 127 total patients)67
7. Endovascular intervention versus surgical revascularization (3 observational; 421 total patients)91,92,94

The literature search revealed many potential studies with the comparators of interest in the IC population; however, many of these studies used different measures for the same outcome. For example, peak performance or walking ability was measured by maximal walking distance (MWD), maximal walking time (MWT), absolute claudication distance (ACD), or peak walking time (PWT). Likewise, claudication onset was measured by initial claudication distance (ICD), pain-free walking distance (PFWD), claudication onset time (COT), or pain-free walking time (PFWT). Also, six studies had more than two treatment arms. Because several of the studies reported results from multiple treatment arms and used different measures for a similar outcome, we constructed an effect size for each relevant arm of each study. We used a random-effects model that was a generalization of the standard random-effects model used in the meta-analysis of effect sizes. Further details are outlined in the Methods section.

### Detailed Synthesis

#### Description of Comparisons

##### 1 Medical Therapy Versus Usual Care

Ten studies (all RCTs) compared medical therapy (cilostazol or pentoxifylline) with placebo in patients who have PAD with IC.25,49,51,73,85-90 These studies included a total of 4103 patients. Of these studies, five were rated good quality and five fair quality. Sample sizes for individual studies ranged from 38 to 1439 patients. Study durations ranged from 12 weeks to 36 months, with a median of 6 months.

The mean age of study participants ranged from 55 to 71 years of age. The proportion of female patients ranged from 0 to 57.6 percent. Five studies49,86,88-90,97 (50%) reported racial and ethnic demographics of the study participants. Few studies reported the treadmill exercise protocol used to measure maximal walking. Few studies reported the use of concomitant medications such as aspirin, antihypertensive medications, and HMG-CoA reductase medications.

Seven studies were conducted within the United States or Canada,25,49,86,88-90,97 with the rest international. Funding source was reported in five studies25,49,87,88,90,97,98 (50%), with four studies funded by the manufacturer of one of the study medications.

##### 2 Exercise Training Versus Usual Care

Twelve studies (ten RCTs, two observational) compared exercise training with usual care in patients who have PAD with IC.66,68-71,73-75,77-79,96 These studies included a total of 754 patients. Of the ten RCTs, four were rated good quality,69,73,77,96 five fair quality,66,68,70,71,74 and one poor quality.79 The two observational studies were both rated poor quality.75,78 Sample sizes for individual studies ranged from 21 to 264 patients. Study durations ranged from 12 weeks to 12 months, with a median of 6 months.

The mean age of study participants ranged from 63 to 76 years of age. The proportion of female patients ranged from 0 to 53 percent. Only two studies69,96 (18%) reported the racial and ethnic demographics of study participants. Few studies reported the treadmill exercise protocol used to measure maximal walking. Few studies reported the use of concomitant medications such as aspirin, antihypertensive medications, and HMG-CoA reductase medications.

Four studies (27%) were conducted within the United States or Canada,68,69,77,96 with the rest international. Funding source was reported in five studies (45%), with those studies funded by government sources or national societies.68-70,77,96

##### 3 Endovascular Intervention Versus Usual Care

Nine studies (five RCTs, four observational studies) compared endovascular intervention with usual care in patients who have PAD with IC.70,72,74,77,91-95 These studies included a total of 1593 patients. Of the RCTs, two were rated good quality77,93 and three fair quality.70,73,95 Three of the observational studies were rated fair quality72,91,94 while one was rated poor.92 Sample sizes for individual studies ranged from 32 to 526 patients. Study durations ranged from 6 months to 24 months.

The mean age of study participants was 62 to 69 years of age. The proportion of female patients ranged from 17.7 to 44.6 percent. Only one study reported the racial and ethnic demographics of the study participants. Few studies reported the treadmill exercise protocol used to measure maximal walking. Few studies reported the use of concomitant medications such as aspirin, antihypertensive medications, and HMG-CoA reductase medications.

Two studies (25%) were conducted within the United States or Canada,77,91 with the rest international. Funding source was reported in all studies, with the majority of studies (six; 67%) funded by government agencies.

A majority of the endovascular procedures for this comparison and the following comparisons consisted of percutaneous transluminal angioplasty (PTA) with or without stent placement, and the type of stent was not specified.

##### 4 Surgical Revascularization Versus Usual Care

One study compared surgical revascularization with usual care in patients who have PAD with IC.76 This observational study included a total of 427 patients and was rated poor quality. The study duration was 5 years and the mean age of the participants was 65 years of age. The study did not report the proportion of female patients or the racial and ethnic demographics of the study participants. The study also failed to report the use of concomitant medications such as aspirin, antihypertensive medications, and HMG-CoA reductase medications. The study was conducted internationally and the funding source was not noted.

##### 5 Endovascular Intervention Versus Exercise Training

Nine studies (all RCTs) compared endovascular intervention with exercise training in patients who have PAD with IC.16,70,74,77,80-84 These studies included a total of 1005 patients. Of these studies, five were rated good quality and five fair quality. Sample sizes for individual studies ranged from 23 to 264 patients. Study durations ranged from 6 months to 72 months, with a median of 6 months.

The mean age of study participants ranged from 62 to 70 years of age. The proportion of female patients ranged from 25 to 45 percent. No study reported the racial and ethnic demographics of the study participants. Few studies reported the treadmill exercise protocol used to measure maximal walking. Few studies reported the use of concomitant medications such as aspirin, antihypertensive medications, and HMG-CoA reductase medications.

One study was conducted within the United States or Canada,77 with the rest international. Funding source was reported in seven studies70,73,77,80,82-84 (70%), with the majority of studies (50%) funded by government agencies.

##### 6 Surgical Revascularization Versus Exercise Plus Medical Therapy

One study compared the use of surgical revascularization with exercise therapy plus pentoxifylline 600 mg twice daily in patients who have PAD with IC.67 This observational study included a total of 127 patients and was rated fair quality. The study duration was 12 weeks and the mean age of the participants was 58 years of age. The study did not report the proportion of female patients or the racial and ethnic demographics of the study participants. The study did not report the treadmill exercise protocol used to measure maximal walking and did not report the use of concomitant medications such as aspirin, antihypertensive medications, and HMG-CoA reductase medications. The study was conducted internationally and the funding source was not noted.

##### 7 Endovascular Intervention Versus Surgical Revascularization

Three studies compared the use of endovascular intervention with surgical revascularization in patients who have PAD with IC.91,92,94 These studies included a total of 421 patients. Of these studies, all three were observational studies (two fair quality, one poor). Sample sizes for individual studies ranged from 153 to 526 patients. Study durations ranged from 6 months to 18 months, with a median of 12 months.

The mean age of study participants was 67 years of age. The proportion of female patients ranged from 20 to 38.8 percent. No studies reported the racial and ethnic demographics of the study participants. No studies reported the treadmill exercise protocol used to measure maximal walking. No studies reported the use of concomitant medications such as aspirin, antihypertensive medications, and HMG-CoA reductase medications. One study was conducted within the United States or Canada,91 with the rest international. Funding source was reported in all three studies, with the majority (67%) funded by government agencies.

#### Effectiveness of Interventions

##### Effect on Cardiovascular Events (Mortality, MI, Stroke)

We identified 16 studies that assessed the effect of various treatments on cardiovascular events in patients with PAD.

###### Medical Therapy Versus Usual Care

Mortality was reported in four studies with a range of followup between 4 months and 3 years49,51,88,89 with death occurring in equal proportions in the medical and usual care groups. Myocardial infarction was reported in two studies49,51 with MI occurring in 8 of 385 patients treated with medical therapy and 2 of 209 patients treated with usual care. Stroke was reported in three studies49,51,88 and occurred in equal proportions in patients treated with medical therapy (1.3%) versus usual care (1.4%).

###### Exercise Training Versus Usual Care

Mortality was reported in two studies68,70 with death occurring in 5.3 percent (6/113 patients) in the control groups, 5.2 percent (6/116 patients) in the exercise groups, and 5.7 percent (5/87 patients) in the intervention group of the Gelin study. MI and stroke were reported in a single study69 with MI occurring in one patient in the home-based exercise group and stroke occurring in one patient in the usual care and supervised exercise groups.

###### Endovascular Intervention Versus Usual Care

Mortality was reported in four studies,70,72,93,94 with a range of followup between 1 and 3 years. One of these studies94 did not report outcomes based on treatment assignment, and the other studies were mixed with one reporting that death occurred more frequently in patients treated with endovascular revascularization (5.2%) than with usual care (3.4%) and the other reporting the opposite (endovascular 2.3% vs. usual care 6.5%).72 Stroke was reported in two studies72,91 but outcomes were reported based on treatment assignment in only one (1.1% PTA vs. 1.4% usual care).72 MI (3.0% PTA vs. 8.8% usual care), coronary artery bypass graft surgery (1.1% PTA vs. 2.3% usual care), coronary intervention (0.8% PTA vs. 2.3% usual care) and carotid intervention (0% vs. 0.9%) were reported in one study.72

###### Surgical Revascularization Versus Usual Care

Mortality was reported in a single observational study,76 with death occurring in 10.4% (27/259) in the surgical revascularization group and 16.7% (28/168) of the usual care group. MI and stroke were not reported.

###### Endovascular Intervention Versus Exercise Training

Mortality was reported in five studies16,70,80,83,84 with a range of followup between 1 and 6 years. All five studies showed either a reduction of mortality in the endovascular group or no difference between groups. MI and stroke were reported in a single study,80 with no MIs occurring in either group, and one stroke occurring in each group throughout the study period.

###### Endovascular Intervention Versus Surgical Revascularization

Mortality was reported in two studies,91,94 with a range of followup between 1 and 2 years, but the results were not presented by treatment group (3% in one study, 8% in the other). Stroke was reported in a single study91 and MI was not reported in any study of endovascular intervention versus surgical revascularization.

##### Analysis of Mortality for All Treatment Comparisons

Table 15 describes the 12 RCTs and 3 observational studies we identified for the analysis of various treatments on mortality in patients with PAD, organized alphabetically. The observational study by Mori76 was not included in the meta-analysis since it was the only study with a surgical revascularization arm and our indirect analysis required at least two studies for each intervention in the model. The study by Giugliano72 also was not included in the meta-analysis since it was the only observational study assessing endovascular intervention compared with usual care. The study by Pell94 was not included in the meta-analysis because it did not report outcomes based on treatment assignment. Therefore, this analysis is limited to the 12 RCTs only (Figure 11). Of note, the Greenhalgh findings are treated as two separate studies since the results for the femoropopliteal and aortoiliac populations are reported separately; i.e., randomization was stratified by anatomic location.80

Table 15 Mortality analysis for all treatment comparisons

Study | Type of Study N Enrolled or Observed^a^ Quality | Outcome Length of Followup | Mortality Results Reported by Authors
Beebe, 1999^49^ | RCT N: 516 Good | Mortality 6 mo | N Cilostazol=346 N death=3 N Placebo=170 N death=2
Gardner, 2002^68^ | RCT N: 52 Fair | Mortality 18 mo | N Supervised exercise=28 N death=1 N Usual care=24 N death=2
Gelin, 2001^70^ | RCT N: 264 Fair | Mortality 12 mo | N Endovascular=87 N death=5 N Exercise=88 N death=5 N Usual Care=89 N death=4
Giugliano 2012^72^ | Observational N: 479 Fair | Cardiovascular death Median followup 21 mo IQR (12.0–29) | Endovascular group N =264 N death=6 N Usual care=215 N death=14
Greenhalgh, 2008^80^ MIMIC Study | RCT N: 93 Fair RCT N: 34 Fair | Mortality 3 mo Mortality 3 mo | Femoropopliteal group N Endovascular=48 N death=2 N Exercise=45 N death=2 Aortoiliac group N Endovascular=19 N death=1 N Exercise=15 N death=2
Hiatt, 2008^88^ Stone, 2008^97^ CASTLE Study | RCT N: 1435 Good | Mortality 36 mo | N Cilostazol=717 N death=49 N Placebo=718 N death=52
Money, 1998^89^ | RCT N: 239 Fair | Mortality 4 mo | N Cilostazol=119 N death=1 N Placebo=120 N death=1
Mori, 2002^76^ | Observational N: 427 Poor | Mortality 5 years | N Surgical revascularization=259 N death=27 N Usual care=168 N death=28
Nordanstig, 2011^83^ | RCT N: 201 Good | Mortality 24 mo | N Endovascular=100 N death=1 N Usual care=101 N death=6
Nylaende, 2007^93^ OBACT Study | RCT N: 56 Good | Mortality 24 mo | N Endovascular=28 N death=1 N Usual care=28 N death=0
Pell, 1997^94^ | Observational N: 201 Fair | Mortality 6 mo | 6 total deaths (number by treatment arm not reported)
Perkins, 1996^84^ | RCT N: 56 Fair | Mortality 6 yr | N Endovascular=30 N death=4 N Exercise=26 N death=6
Soga, 2009^51^ | RCT N: 78 Good | Mortality 24 mo | N Cilostazol=39 N death=1 N Placebo=39 N death=2
Spronk, 2009^16^ | RCT N: 150 Fair | Mortality 12 mo | N Endovascular=75 N death=3 N Exercise=75 N death=5

a Number of patients in the study arms of interest.

Abbreviations: mo=month/months; RCT=randomized controlled trial; yr=year/years.

Figure 11 Network meta-analysis of treatment effects versus usual care and each other on mortality in IC patients

Abbreviation: CI=confidence interval.

This figure displays a forest plot of the twelve RCTs of all-cause mortality in IC patients comparing the effect of multiple treatments with usual care and with each other. The result was an estimated odds ratio for cilostazol versus control of 0.91 (95% CI, 0.62 to 1.35, p=0.65) favoring cilostazol. The estimated odds ratio for exercise versus control was 0.84 (CI, 0.34 to 2.07, p=0.70) favoring exercise. The estimated odds ratio for exercise versus cilostazol was 0.65 (CI, 0.27 to 1.55, p=0.33) favoring exercise. The estimated odds ratio for endovascular versus control was 0.91 (CI, 0.34 to 2.45, p=0.86) favoring endovascular intervention. The estimated odds ratio for endovascular versus cilostazol was 0.71 (CI, 0.27 to 1.84, p=0.48) favoring endovascular intervention. The estimated odds ratio for endovascular versus exercise was 0.77 (CI, 0.39 to 1.54, p=0.47) favoring endovascular intervention.

The random-effects network meta-analysis of the 12 RCTs16,49,51,68-70,80,83,84,88,89,93 of mortality is shown in Figure 11 for each treatment comparison. No specific treatment was found to have a statistically significant effect. The wide confidence intervals make conclusions less certain, and therefore the SOE is rated low. The Soga et al. study compared cilostazol with placebo but included endovascular surgery in each arm. As a sensitivity analysis, we ran a random-effects meta-analysis without the Soga study, and the odds ratio for cilostazol versus control was essentially the same (OR 0.93; 95% CI, 0.63 to 1.38).

##### Effect on Maximal Walking Measures

We identified 25 unique studies that reported the walking measures MWD, ACD, or PWT. Results by study comparison are listed in Table 16. There was significant heterogeneity in the study protocols and data reporting.

Table 16 Calculated effect size: maximal walking measures

Study | Type of Study N Analyzed^a^ Quality | Outcome Length of Followup | Results Reported by Authors | Calculated Effect Size^b^
Medical therapy vs. usual care
Beebe, 1999^49^ | RCT N: 316 Good | MWD (m) 6 mo | Cilostazol 100 mg Mean geometric % change: 1.51 Placebo: 1.15 | ES: 0.46 EffSE: 0.10
Belcaro, 2002^85^ | RCT N: 53 Fair | MWD (m) 6 mo | Mean MWD (SD) Pentoxifylline: baseline 56 (8) 3 mo 122 (10) Placebo: baseline 59 (12) 3 mo 99 (13) | ES: 4.89 EffSE: 0.19
Dawson, 1998^86^ | RCT N: 66 Good | ACD (m) 12 wk | Mean change from baseline least square (SE) Cilostazol: 42.6 (8.2) Placebo: 3.5 (11.7) | ES: 0.72 EffSE: 0.14
Dawson, 2000^25^ | RCT N: 643 Fair | MWD (m) 6 mo | Mean change in MWD (SD) Cilostazol 107 (158) Pentoxifylline 64 (127) Placebo 65 (135) | ES (cilostazol): 0.91 EffSE: 0.07 ES (pentoxifylline): 0.55 EffSE: 0.07
De Sanctis, 2002^87,98^ | RCT N: 101 Poor | TWD (m) 12 mo | Mean % change in TWD Pentoxifylline: 404% Placebo: 280% | ES: 0.41 EffSE: 0.18
Hobbs, 2007^73^ INEXACT Study | RCT N: 18 Good | ACD (m) 6 mo | Ratio of 6 mo: baseline ACD (SD) Cilostazol: 1.69 (1.55) Usual care: 1.09 (0.34) | ES: 1.69 EffSE: 0.33
Money, 1998^89^ | RCT N: 212 Fair | ACD (m) 4 mo | Mean ACD (SE) Cilostazol: baseline 236.9 (13.6) 4 mo 332.6 (20.0) Placebo: baseline 244.3 (13.7) 4 mo 281.1 (19.2) | ES: 1.39 EffSE: 0.10
Strandness, 2002^90^ | RCT N: 377 Fair | MWD (m) 6 mo | Cilostazol 100 mg Estimated treatment effect: 1.21 (1.09 to 1.35) | ES: 0.46 EffSE: 0.90
Exercise training vs. usual care
Treat-Jacobson, 2009^96^ | RCT N: 15 Good | MWD (m) 24 wk | Mean change in MWD (SD) Exercise: 294.4 (162.2) Usual care: 73.3 (65.6) | ES: 2.38 EffSE: 0.44
Gardner, 2002^68^ | RCT N: 31 Fair | ACD (m) 18 months | Percent change in ACD Exercise: 80% Control: 0% | ES: 1.13 EffSE: 0.24
Gardner, 2011^69^ | RCT N: 63 Good | PWT (sec) 12 wk | Mean change in PWT (SD) Exercise: 215 (207) Usual care: -10 (176) | ES: 1.19 EffSE: 0.27
Gelin, 2001^70^ | RCT N: 149 Fair | MWD (m) 12 mo | Mean MWD (SD) Exercise: baseline 258 (142) 1 yr 247 (111) Control: baseline 272 (153) 1 yr 261 (131) | ES: -0.08 EffSE: 0.10
Gibellini, 2000^71^ | RCT N: 37 Fair | ACD (m) 6 mo | ACD (SD) Exercise: baseline 203 (66.1) 6 mo 393.6 (208.8) Control: baseline 230.1 (109.8) 6 mo 276.4 (191.2) | ES: 0.98 EffSE: 0.44
Hobbs, 2006^74^ EXACT Study | RCT N: 14 Fair | ACD (m) 6 mo | Ratio of 6 mo: baseline ACD (SD) Exercise: 1.45 (0.80) Usual care: 1.09 (0.34) | ES: 1.20 EffSE: 0.33
Hobbs, 2007^73^ INEXACT Study | RCT N: 18 Good | ACD (m) 6 mo | Overall effect at 6 mo (ACD) Exercise: 1.33 Best medical therapy: 1.0 | ES: 0.59 EffSE: 0.48
Lee, 2007^75^ | Observational N: 70 Poor | MWD (m) 6 mo | Median MWD (IQR) Exercise: baseline 117.6 (73.5 to 205.8) 6 mo 300 (143.8 to 300) Usual care: baseline 152.2 (76.7 to 279.3) 6 mo 185 (102.0 to 300) | Unable to compute (no SD or p-value)
Murphy, 2012^77^ CLEVER Study | RCT N: 58 Good | PWT (min) 6 mo | Mean change in PWT (SD) Exercise: 5.8 (4.6) Usual care: 1.2 (2.6) | ES: 1.04 EffSE: 0.29
Sugimoto, 2010^78^ | Observational N: 100 Poor | ACD (m) 6 mo | Mean ACD (SD) Exercise: baseline 143 (90) 6 mo 257 (161) Usual care: baseline 249 (177) 6 mo 317 (168) | ES: 0.70 EffSE: 0.13
Tsai, 2002^79^ | RCT N: 53 Poor | PWT (min) 3 mo | Mean PWT (SD) Exercise: baseline 7.4 (3.9) 3 mo 12.5 (3.7) Control: baseline 7.2 (3.2) 3 mo 7.6 (3.8) | ES: 1.25 EffSE: 0.30
Endovascular intervention vs. usual care
Gelin, 2001^70^ | RCT N: 152 Fair | MWD (m) 12 mo | Mean MWD (SD) Baseline: Revascularization 274 (172), control 272 (153) 1 year: Revascularization 344 (169), control 261 (131) | ES: 0.51 EffSE: 0.13
Hobbs, 2006^74^ EXACT Study | RCT N: 16 Fair | ACD (m) 6 mo | Median change in ACD (IQR) Endovascular: 513 (110 to 1000) Usual care: 61 (75 to 435) | ES: 0.47 EffSE: 0.51
Murphy, 2012^77^ CLEVER Study | RCT N: 61 Good | PWT (min) 6 mo | Mean change in PWT (SD) Endovascular: 3.7 (4.9) Usual care: 1.2 (2.6) | ES: 0.57 EffSE: 0.28
Nylaende, 2007^93^ OBACT Study | RCT N: 56 Good | MWD (m) 24 mo | Mean MWD (SD) Baseline: Endovascular 323.9 (231.5), usual care 265.4 (173.5) 2 year: Endovascular 539.2 (144.3), usual care 319.5 (220.4) | ES: 0.51 EffSE: 0.19
Endovascular intervention vs. exercise training
Gelin, 2001^70^ | RCT N: 149 Fair | MWD (m) 12 mo | Mean MWD (SD) Baseline: Revascularization (274 (172), exercise 258 (142), control 272 (153) 1 year: Revascularization 344 (169), exercise 247 (111), control 261 (131) | ES (endo): 0.51 EffSE: 0.13 ES (ex): -0.08 EffSE: 0.10
Greenhalgh, 2008^80^ MIMIC Study | RCT N: 94 Fair | MWD (m) 24 mo | Mean change in MWD [underlined: Femoropopliteal group] Endovascular + exercise: 224 Exercise: 150 [underlined: Aortoiliac group] Endovascular + exercise: 354 Exercise: 168 | ES (femor): 0.43 EffSE: 0.21 ES (aorto): 0.70 EffSE: 0.36
Hobbs, 2006^74^ EXACT Study | RCT N: 16 Fair | ACD (m) 6 mo | Median Change in ACD (IQR) Endovascular: 513 (110 to 1000) Exercise: 13 (69 to 352) | ES: 0.76 EffSE: 0.52
Kruidenier, 2011^81^ | RCT N: 61 Good | ACD (m) 6 mo | Mean ACD (SD) Baseline: Endovascular 343.3 (247.9), endovascular + exercise 293.4 (189.6) 6 month: Endovascular 685.0 (313.5), endovascular + exercise 956.3 (490.4) | ES: 0.63 EffSE: 0.25
Mazari, 2012^82^ | RCT N: 109 Good | MWD (m) 6 mo | Median MWD (IQR) Baseline: Endovascular 77.62 (49.16 to 116.11), exercise 83.41 (58.32 to 141.65) 6 mo: Endovascular 146.15 (67.45 to 215.0), exercise 215.0 (104.97 to 215.0) | ES (endo): 0.78 EffSE: 0.12 ES (ex): 0.96 EffSE: 0.15 ES (endo+ex): 1.90 EffSE: 0.12
Murphy, 2012^77^ CLEVER Study | RCT N: 79 Good | PWT (min) 6 mo | Mean change in PWT (SD) Endovascular 3.7 (4.9) Exercise 5.8 (4.6) Usual care 1.2 (2.6) | ES: -0.48 EffSE: 0.23
Perkins, 1996^84^ | RCT N: 56 Fair | MWD (m) 6 yr | Median MWD (SE) Baseline: Endovascular 82.3735 (18.8482), exercise 104.014 (20.924) 70 mo: Endovascular 181.5 (53.8), exercise 124.3 (46.8) | ES (endo): 0.11 EffSE: 0.18 ES (ex): 0.4 EffSE: 0.20
Spronk, 2009^16^ | RCT N: 150 Fair | MWD (m) 12 mo | Mean improvement score (99% CI) Endovascular : 826 (680 to 970) Exercise: 1034 (896 to 1170) | ES (endo): 3.56 EffSE: 0.13 ES (ex): 5.36 EffSE: 0.11
Surgical revascularization vs. exercise plus medical therapy (pentoxifylline)
Drozdz 2001^67^ | Prospective Cohort N: 127 Fair | MWT (min) 12 wk | Mean MWT (SD) Surgical revascularization; 1. Baseline: 3.70 (1.10); 2. 12 wk: >15; Usual care; 1. Baseline: 4.90 (0.40); 2. 12 wk: 11.8 (1.7) | Unable to compute (no exact p-value, categorical value for 12-wk surgical result)
Endovascular intervention vs. surgical revascularization
No studies

a Number of patients in the study arms of interest.

b Values used in meta-analysis appear in bold.

Abbreviations: ACD=absolute claudication distance; EffSE=standard error of effect; endo=endovascular; ES=effect size; ex=exercise; IQR=interquartile range; m=meters; min=minute/minutes; mo=month/months; MWD=maximal walking distance; MWT=maximal walking time; PWT=peak walking time; RCT=randomized controlled trial; SD=standard deviation; sec=second/seconds; TWD=total walking distance; wk=week/weeks.

###### Medical Therapy Versus Usual Care

Maximal walking measures were reported in eight studies: cilostazol (five studies), pentoxifylline (two), and both (one). Seven of these studies reported MWD or ACD; no studies reported PWT. We included these seven studies (three good quality, four fair)25,49,73,85,86,89,90 that reported MWD or ACD with median duration of treatment of 6 months in the random-effects meta-analysis (Figure 12). The one study not included in the analysis (De Sanctis et al.87,98) reported total walking distance at 12 months and reported a mean percentage change as 404% in the pentoxifylline group and 280% in the placebo group. We calculated an effect size (standard error) of 0.408 (0.175) for this comparison.

Figure 12 Network meta-analysis of treatment effects versus usual care on walking distance in IC patients

Abbreviation: CI=confidence interval.

This figure displays a forest plot for 16 studies that compared the effect of multiple treatments on maximal walking distance. The results show summary effect sizes of 0.89 (95% CI, 0.06 to 1.71, p=0.04) for exercise training; 0.62 (CI, -0.21 to 1.45, p=0.14) for cilostazol; 1.70 (CI, 0.36 to 3.04 p=0.01) for pentoxifylline; 0.41 (CI, -0.54 to 1.36, p=0.40) for endovascular intervention; and 1.08 (CI, -0.37 to 2.53, p=0.14) for endovascular intervention plus exercise.

###### Exercise Training Versus Usual Care

Maximal walking measures were reported in 11 studies: MWD (3 studies), ACD (5), and PWT (3). We included five RCTs (two good quality, three fair quality)68,71,73,74,96 in the random-effects meta-analysis (Figure 12). The Gelin study70 was not included since it reported MWD results at 12 months; we calculated an effect size (standard error [SE]) of -0.08 (0.10) for this study, which essentially shows no difference in effect between the two treatments. The observational study by Sugimoto78 reported ACD results at 6 months and the calculated effect size (SE) was 0.70 (0.13) showing a large effect of exercise training over usual care. We were unable to calculate an effect size for Lee et al. (2007)75 since it did not report the standard deviation or exact p-value; that study found that the improvement in MWD (183 meters) was higher in the exercise group compared to usual care (33 meters) after 6 months. The three studies reporting PWT found improvements in the group that received supervised exercise compared to usual care.69,77,79

###### Endovascular Intervention Versus Usual Care

Maximal walking measures were reported in four studies: MWD (two studies), ACD (one), and PWT (one). Two of these studies (one good quality, one fair)74,93 reporting MWD or ACD were included in the random-effects meta-analysis (Figure 12). The Gelin study70 reported MWD results at 12 months; we calculated an effect size (SE) of 0.51 (0.13) for this study that showed a moderate effect of endovascular intervention compared to usual care. The study by Murphy et al. (2012)77 reported an improvement in PWT in the endovascular group compared to usual care, calculated effect size (SE) of 5.66 (0.278).

###### Endovascular Intervention Versus Exercise Training

Maximal walking measures were reported in eight studies: MWD (five studies), ACD (two), and PWT (one). Five of these studies (one good quality, three fair)16,74,82,84 were included in the random-effects meta-analysis (Figure 12). The Gelin study70 reported MWD results at 12 months and showed a larger effect in the endovascular group compared to the exercise group. The Greenhalgh study80 reported mean change in the MWD at 24 months with the group in the endovascular plus exercise group having a moderate effect compared to exercise alone in the femoropopliteal patients (ES=0.43) and a large effect in the aortofemoral patients (ES=0.70). In the Murphy study reporting PWT change at 6 months,77 mean change in the endovascular group was 3.7 min (SD 4.9) and the exercise group was 5.8 min (SD 4.6), p=0.04. Our calculated effect size of endovascular intervention compared to exercise was -0.48 (SE 0.23), which means there was a moderate effect favoring exercise.

###### Surgical Revascularization Versus Exercise Plus Medical Therapy

One study reported MWT as a measure of maximal walking.67 MWT (minutes) improved from 4.9 (SD 0.4) to 11.8 (SD 1.7) in the exercise plus medical therapy (pentoxifylline) arm and from 3.7 (SD 1.1) to >15 in the surgical revascularization arm. We were unable to compute an effect size since the 12-week result in the surgical arm was a categorical (nonexact) value and the authors did not report an exact p-value.

###### Endovascular Intervention Versus Surgical Revascularization

No study reported measures of MWD for this comparison.

##### Analysis of Walking Measures

Table 16 presents the 25 studies that reported walking measures MWD, ACD, or PWT, organized alphabetically by study comparison. Of these studies, 16 studies were included in the random-effects network meta-analysis (Figure 12).

We conducted a random-effects meta-analysis with 16 studies16,25,49,68,71,73,74,82,84-86,89,90,93,96 to compare the multiple treatment arms on continuous measures (PROC NLMIXED). The results show summary effect sizes of 0.89 (95% CI, 0.06 to 1.71, p=0.04) for exercise training; 0.62 (CI, -0.21 to 1.45, p=0.14) for cilostazol; 1.70 (CI, 0.36 to 3.04 p=0.01) for pentoxifylline; 0.41 (CI, -0.54 to 1.36, p=0.40) for endovascular intervention; and 1.08 (CI, -0.37 to 2.53, p=0.14) for the combination of endovascular intervention and exercise. These effects are all relative to usual care and are summarized in Figure 12.

Thus, large effects were seen with exercise training (moderate SOE; nine studies), pentoxifylline (insufficient SOE due to imprecision and inconsistency; two studies), and the combination of endovascular intervention and exercise (low SOE; 2 studies). Moderate effects were seen with endovascular intervention (moderate SOE; five studies) and cilostazol (low SOE; six studies). Clinically, this equates to an improvement in MWD or ACD of 135 meters for exercise training, 63 meters for endovascular intervention, and 166 for the combination of endovascular intervention and exercise. For the medical therapies, this equates to an improvement in MWD or ACD of 95 meters for cilostazol and 260 meters for pentoxifylline.

Since the level of evidence for pentoxifylline was insufficient due to inconsistency and imprecision, we ran a sensitivity analysis removing the pentoxifylline studies.25,85 The results show summary effect sizes of 0.98 (95% CI, 0.23 to 1.74, p=0.01) for exercise training; 0.61 (CI, -0.20 to 1.42, p=0.14) for cilostazol; 0.51 (CI, -0.35 to 1.37, p=0.25) for endovascular intervention; and 1.20 (CI, -0.11 to 2.50, p=0.07) for the combination of endovascular intervention and exercise. These effects are all relative to usual care and are summarized in Figure 13.

Figure 13 Network sensitivity meta-analysis of treatment effects versus usual care on walking distance in IC patients

Abbreviation: CI=confidence interval.

This figure displays a sensitivity meta-analysis of treatment effects versus usual care in which the pentoxifylline studies were removed due to inconsistent and imprecise results. The results show summary effect sizes of 0.98 (95% CI, 0.23 to 1.74, p=0.01) for exercise training; 0.61 (CI, -0.20 to 1.42, p=0.14) for cilostazol; 0.51 (CI, -0.35 to 1.37, p=0.25) for endovascular intervention; and 1.20 (CI, -0.11 to 2.50, p=0.07) for endovascular intervention and exercise.

Similar to the full analysis, large effects were seen with exercise training (moderate SOE; nine studies) and the combination of endovascular intervention plus exercise (low SOE; 2 studies). Moderate effects were seen with endovascular intervention (moderate SOE; five studies) and cilostazol (low SOE; six studies). Clinically, this equates to an improvement in MWD or ACD of 150 meters for exercise training, 93 meters for cilostazol, 78 meters for endovascular intervention, and 184 for the combination of endovascular intervention plus exercise.

When indirectly compared against each other, none of the treatment arms were found to be significantly different. This is summarized in Figure 14, with the effect sizes favoring the first treatment (negative values) on the left and the second treatment (positive values) on the right. There was a small effect between cilostazol and endovascular intervention (ES=-0.21, favoring cilostazol) and between exercise and cilostazol (ES=-0.27, favoring exercise). There were medium effects seen between exercise and endovascular interventions (ES=-0.47, favoring exercise), between cilostazol and the combination of endovascular intervention with exercise (ES=0.46, favoring the combination), between pentoxifylline and the combination of endovascular with exercise (ES=-0.62, favoring pentoxifylline), as well as between endovascular and the combination of endovascular with exercise (ES=0.67, favoring the combination). There were large effects seen between cilostazol and pentoxifylline (ES=1.08, favoring pentoxifylline), exercise and pentoxifylline (ES=0.82, favoring pentoxifylline), and between pentoxifylline and endovascular intervention (ES=-1.29, favoring pentoxifylline).

Figure 14 Network meta-analysis of treatment effects versus each other on walking distance in IC patients

Abbreviation: CI=confidence interval.

This figure displays a forest plot for 16 studies that compared the effect of multiple treatments on maximal walking distance. When indirectly compared against each other, none of the treatment arms were found to be significantly different. The effect size for cilostazol versus pentoxifylline was 1.08 (95% CI, -0.35 to 2.52, p=0.14), favoring pentoxifylline. The effect size for cilostazol versus endovascular was -0.21 (CI, -1.33 to 0.92, p=0.72), favoring cilostazol. The effect size for cilostazol versus endovascular plus exercise was 0.46 (CI, -1.10 to 2.03, p=0.56), favoring endovascular plus exercise. The effect size for pentoxifylline versus endovascular was -1.29 (CI, -2.84 to 0.26, p=0.10), favoring pentoxifylline. The effect size for pentoxifylline versus endovascular plus exercise was -0.62 (CI, -2.51 to 1.27, p=0.52), favoring pentoxifylline. The effect size for exercise versus cilostazol was -0.27 (CI, -1.29 to 0.76, p=0.61), favoring exercise. The effect size for exercise versus pentoxifylline was 0.82 (CI, -0.67 to 2.30, p=0.28), favoring pentoxifylline. The effect size for exercise versus endovascular was -0.47 (CI, -1.40 to 0.46, p=0.32), favoring exercise. The effect size for exercise versus endovascular plus exercise was 0.20 (CI, -1.23 to 1.63, p=0.79), favoring endovascular plus exercise. The effect size for endovascular versus endovascular plus exercise was 0.67 (CI, -0.71 to 2.05, p=0.34), favoring endovascular plus exercise.

Again, we ran a sensitivity analysis removing the pentoxifylline studies and had similar results to the full analysis (Figure 15). When indirectly compared against each other, none of the treatment arms were found to be significantly different, with effect sizes favoring the first treatment (negative values) on the left and the second treatment (positive values) on the right. There was a minimal effect between cilostazol and endovascular intervention (ES=-0.10, no difference). There was a small effect between exercise and the combination endovascular with exercise (ES=0.22, favoring the combination) and between exercise and cilostazol (ES=-0.37, favoring exercise). There were medium effects seen between exercise and endovascular interventions (ES=-0.47, favoring exercise), between cilostazol and the combination of endovascular with exercise (ES=0.58, favoring the combination), as well as between endovascular and the combination of endovascular with exercise (ES=0.68, favoring the combination).

Figure 15 Network sensitivity meta-analysis of treatment effects versus each other on walking distance in IC patients

Abbreviation: CI=confidence interval.

This figure displays a sensitivity meta-analysis of treatment effects versus each other in which the pentoxifylline studies were removed due to inconsistent and imprecise results. The results show an effect size for cilostazol versus endovascular of -0.10 (95% CI, -1.16 to 0.96, p=0.85), favoring cilostazol. The effect size for cilostazol versus endovascular and exercise was 0.58 (CI, -0.84 to 2.01, p=0.42), favoring endovascular and exercise. The effect size for exercise versus cilostazol was -0.37 (CI, -1.34 to 0.60, p=0.45), favoring exercise. The effect size for exercise versus endovascular was -0.47 (CI, -1.31 to 0.36, p=0.27), favoring exercise. The effect size for exercise versus endovascular and exercise was 0.22 (CI, -1.05 to 1.50, p=0.73), favoring endovascular and exercise. The effect size for endovascular versus endovascular and exercise was 0.68 (CI, -0.55 to 1.91, p=0.28), favoring endovascular and exercise.

We consider the network sensitivity meta-analyses without the pentoxifylline studies (Figures 13 and 15) to be the definitive analysis for the following reasons. First, there were few pentoxifylline studies published since 1995, with 6 studies excluded from the analysis because they were conducted prior to current clinical practice where secondary prevention of cardiovascular events includes treatment of hypertension, diabetes, hyperlipidemia, and tobacco use. Second, the studies that were included in the full analysis were inconsistent and imprecise (i.e., insufficient SOE), and therefore the effect sizes shown in Figure 14 comparing pentoxifylline with usual care and other treatments were also imprecise. Third, the ACC/AHA guidelines recommend pentoxifylline as an alternative therapy to cilostazol since the clinical effectiveness for IC is marginal and not well established.2

##### Effect on Claudication Onset Measures

Twenty-one unique studies reported claudication onset measures ICD, PFWD, PFWT, or COT. Results by study comparison are listed in Table 17. There was significant heterogeneity in the study protocols and data reporting.

Table 17 Calculated effect size: claudication onset measures

Study | Type of Study N Analyzed^a^ Quality | Outcome Length of Followup | Results Reported by Authors | Calculated Effect Size^b^
Medical therapy vs. usual care
Beebe, 1999^49^ | RCT N: 316 Good | PFWD (m) 6 mo | Mean geometric % change PFWD Cilostazol 100: 1.51 Cilostazol 50: 1.38 Placebo: 1.15 | Unable to compute (no exact p-value, SD in wrong units)
Dawson, 1998^86^ | RCT N: 66 Good | ICD (m) 12 wk | ICD (SE) Cilostazol: baseline 71.2 (6.0) 3 mo 112.5 (13.8) Placebo: 77.7 (8.4) 3 mo 84.6 (13.7) | ES (cilostazol): 0.68 EffSE: 0.25
Dawson, 2000^25^ | RCT N: 643 Fair | PFWD (m) 6 mo | Mean % change in PFWD Pentoxifylline: 74 (106) Cilostazol: 94 (127) Placebo: 57 (93) | ES (pentoxifylline): 0.17 EffSE: 0.10 ES (cilostazol): 0.38 EffSE: 0.10
Hobbs, 2007^73^ INEXACT Study | RCT N: 18 Good | ICD (m) 6 mo | Ratio of 6 mo: baseline ICD (SD) Cilostazol: 3.34 (4.23) Best medical therapy: 1.23 (0.73) | ES (cilostazol): 0.72 EffSE: 0.49
Money, 1998^89^ | RCT N: 212 Fair | ICD (m) 4 mo | % change in ICD compared to placebo Cilostazol: 27% | Unable to compute (no exact p-value or SD)
Exercise training vs. usual care
Treat-Jacobson, 2009^96^ | RCT N: 31 Good | PFWD (m) 24 wk | Change in PFWD (SD) Walking: 155.1 (180.7) Usual care: 10.9 (27.4) Arm ergometry: 39.7 (97.2) Walking + arm ergometry: 21.6 (81.3) | ES: 1.30 EffSE: 0.51
Crowther, 2008^66^ | RCT N: 21 Fair | PFWT (sec) 12 mo | Mean PFWT in seconds (SD): Exercise: baseline 132.8 (61.1) 1 yr 360.0 (188.3) Control: 115.9 (99.5) 1 yr 166.3 (89.4) | ES: 1.06 EffSE: 0.47
Gardner, 2002^68^ | RCT N: 31 Fair | ICD (m) 18 mo | Percent Change in ICD Exercise: 189% Control: 0% | ES: 1.32 EffSE: 0.24
Gardner, 2011^69^ | RCT N: 63 Good | COT (sec) 12 wk | COT change from baseline (SD) Supervised exercise: 165 (173) Control: -16 (125) Home exercise: 134 (197) | ES: 1.06 EffSE: 0.47
Gibellini, 2000^71^ | RCT N: 37 Fair | ICD (m) 6 mo | Mean ICD (SD) Exercise: baseline 116.8 (48.2) 6 mo 351.4 (209.5) Control: 111.6 (64.6) 6 mo 114.5 (79.6) | ES: 2.14 EffSE: 0.79
Hobbs, 2006^74^ EXACT Study | RCT N: 14 Fair | ICD (m) 6 mo | Median ICD (IQR) Exercise: baseline 59 (35 to 63) 6 mo 92 (47 to169) Best medical therapy: baseline 47 (30 to 118) 6 mo 56 (45 to 325) Median ICD (range) Usual care: baseline 59 (48 to 72) 6 mo 64 (47 to 77) Usual care + exercise: baseline 60 (45 to 95) 6 mo 127 (62 to 180) | ES: 0.01 EffSE: 0.54
Hobbs, 2007^73^ INEXACT Study | RCT N: 18 Good | ICD (m) 6 mo | Overall effect at 6 mo (ICD) Exercise: 1.80 Best medical therapy: 1.0 | ES: 0.34 EffSE: 0.48
Lee, 2007^75^ | Observational N: 70 Poor | ICD (m) 6 mo | Median ICD (range) Exercise: baseline 58.5 (39.2 to 112.7) 6 mo 107.5 (52.5 to 153.8) Usual care: baseline 78.4 (39.2 to 131.2) 6 mo 75 (45 to 180) | Unable to compute (no SD or p-value)
Murphy, 2012^77^ CLEVER Study | RCT N: 58 Good | COT (sec) 6 mo | Mean change in COT from baseline (SD) Exercise: 3.0 (2.9) Usual care: 0.7 (1.1) | ES: 0.70 EffSE: 0.28
Tsai, 2002^79^ | RCT N: 53 Poor | COT (min) 3 mo | Mean COT (SD) Exercise: baseline 3.3 (3.1) 3 mo 6.2 (2.7), Usual care: baseline 2.9 (2.6) 3 mo 3.2 (3.4) | ES: 0.74 EffSE: 0.28
Endovascular intervention vs. usual care
Hobbs, 2006^74^ EXACT Study | RCT N: 16 Fair | ICD (m) 6 mo | Median ICD (IQR) Baseline: Endovascular 84 (43 to 127), best medical therapy 47 (30 to 118) 6 mo: Endovascular 698 (147 to 1000), best medical therapy 56 (43 to 325) | ES: 0.74 EffSE: 0.52
Koivunen, 2008^92^ | Observational N: 129 Poor | PFWD (m) 12 mo | Median PFWD (IQR) Baseline: Endovascular 100 (50 to 200), surgery 100 (50 to 200), usual care 200 (100 to 500) 12 mo: Endovascular 400 (100 to 10,000), surgery 2250 (2250 to 10,000), usual care 200 (100 to 1000) | Distribution of values are unusual therefore effect sizes cannot be computed
Murphy, 2012^77^ CLEVER Study | RCT N: 61 Good | COT (sec) 6 mo | Mean change in COT (SD) Endovascular 3.6 (4.2) Usual Care 0.7 (1.1) | ES: 0.88 EffSE: 0.28
Nylaende, 2007^93^ OBACT Study | RCT N: 56 Good | PFWD (m) 24 mo | Mean PFWD (SD) Baseline: Endovascular 93.5 (72.9) usual care 69.6 (54.2), 24 mo: Endovascular 435.0 (223.8), usual care: 174.9 (171.8) | ES: 1.28 EffSE: 0.27
Whyman, 1997^95^ | RCT N: 19 Fair | ICD (m) 24 mo | Median ICD (IQR) Baseline: Endovascular 56 (33 to 133), usual care 78 (58 to 100) 24 mo: Endovascular 383 (85 to 667), usual care 333 (106 to 667) | ES: 0.25 EffSE: 0.18
Endovascular intervention vs. exercise training
Greenhalgh, 2008^80^ MIMIC Study | RCT N: 94 Fair | ICD (m) 24 mo | Adjusted HR (95% CI) [underlined: Femoropopliteal group] Endovascular: 3.11 (1.42 to 6.81) Exercise + optimal medical therapy 1.0 [underlined: Aortoiliac group] Endovascular: 3.6 (1.0 to 12.8) Exercise + optimal medical therapy 1.0 | ES (femor): 0.61 EffSE: 0.21 ES (aorto): 0.70 EffSE: 0.36
Hobbs, 2006^74^ EXACT Study | RCT N: 16 Fair | ICD (m) 6 mo | Median ICD (IQR) Baseline: Endovascular 84 (43 to 127), exercise 59 (35 to 63) 6 month: Endovascular 698 (147 to 1000), exercise 92 (47 to 169) | ES: 0.73 EffSE: 0.52
Mazari, 2012^82^ | RCT N: 109 Good | ICD (m) 12 mo | Median ICD (IQR) Baseline: Endovascular 31.30 (20.70 to 63.13), exercise 42.71 (26.65 to 74.17) 12 mo: Endovascular 75.80 (46.07 to 209.82), exercise 103.15 (64.1 to 129.3) | ES (endo): 0.58 EffSE: 0.17 ES (ex): 0.61 EffSE: 0.06 ES (endo+ex): 0.49 EffSE: 0.16
Murphy, 2012^77^ CLEVER Study | RCT N: 79 Good | COT (sec) 6 mo | Mean change in COT from baseline in seconds (SD) Endovascular 3.6 (4.2) Exercise 3.0 (2.9) Usual Care 0.7 (1.1) | ES: 0.18 EffSE: 0.23
Spronk, 2009^16^ | RCT N: 150 Fair | PFWD (m) 12 mo | Mean improvement in PFWD (99% CI) Endovascular 806 (646 to 960) Exercise 943 (786 to 1099) | ES (endo): 1.28 EffSE: 0.12 ES (ex): 1.52 EffSE: 0.11
Surgical revascularization vs. exercise training plus medical therapy (pentoxifylline)
Drozdz, 2001^67^ | Prospective Cohort N: 127 Fair | COT (min) 12 wk | Mean COT (SD) Baseline: Usual care 2.8 (0.3), surgical revascularization 1.4 (0.5) 12 wk: Usual care 7.30 (0.9), surgical revascularization >10 | Unable to compute (no exact p-value, categorical value for 12-wk surgical result)
Endovascular intervention vs. surgical revascularization
No studies

a Number of patients in the study arms of interest.

b Values used in meta-analysis appear in bold.

Abbreviations: COT=claudication onset time; EffSE=standard error of effect; ES=effect size; ICD=initial claudication distance; IQR=interquartile range; m=meters; min=minute/minutes; mo=month/months; PFWD=pain-free walking distance; PFWT=pain-free walking time; RCT=randomized controlled trial; SD=standard deviation; wk=week/weeks.

###### Medical Therapy Versus Usual Care

Claudication onset measures were reported in five studies: ICD (three studies) and PFWD (two); no studies reported COT. Three of these studies (two good quality, one fair) were included in the random-effects meta-analysis (Figure 16).25,73,86 For two studies,49,89 we were unable to calculate an effect size since the results provided did not contain a standard deviation or exact p-value. Both studies showed mild increases in the PFWD and ICD on cilostazol compared to placebo.

Figure 16 Network meta-analysis of treatment effects versus usual care and each other on claudication distance in IC patients

Abbreviation: CI=confidence interval.

This figure displays a forest plot of the 12 studies that compared the effect of multiple treatments on initial claudication distance or pain-free walking distance. The effect size for usual care versus cilostazol was 0.63 (95% CI, -0.02 to 1.29, p=0.059), favoring cilostazol. The effect size for usual care versus exercise training was 0.69 (CI, 0.23 to 1.15, p=0.003), favoring exercise training. The effect size for usual care versus endovascular intervention was 0.79 (CI, 0.29 to 1.29, p=0.002), favoring endovascular intervention. The effect size for cilostazol versus exercise training was 0.06 (CI, -0.67 to 0.79, p=0.874), favoring exercise training. The effect size for cilostazol versus endovascular intervention was 0.16 (CI, -0.59 to 0.91, p=0.680), favoring endovascular intervention. The effect size for exercise versus endovascular intervention was 0.10 (CI, -0.38 to 0.57, p=0.685), favoring endovascular intervention.

###### Exercise Training Versus Usual Care

Claudication onset measures were reported in 10 studies: ICD (5 studies), PFWD (1), PFWT (1), and COT (3). Five of these studies (two good quality, three fair)68,71,73,74,96 reporting ICD or PFWD were included in the random-effects meta-analysis. The effect size for Lee et al.75 could not be calculated due to no reported SD or p-value. The five studies reporting timing measures showed an improvement with supervised exercise compared with usual care with moderate to large effect sizes (SE) ranging from 0.70 (0.28) to 1.06 (0.47).

###### Endovascular Intervention Versus Usual Care

Claudication onset measures were reported in five studies: ICD (two studies), PFWD (two), and COT (one). A random-effects meta-analysis included three of these studies (one good quality, two fair).74,93,95 The effect size for the Koivunen et al. study92 could not be calculated since the distribution of values in each study arm was unusual. The Murphy et al. (2012) study77 reported mean change in COT (SD) of 3.6 (4.2) in the endovascular arm, and 0.7 (1.1) in the usual care arm. Our calculated effect size was 0.88 (SD 0.28), which means a large effect significantly favoring endovascular intervention over usual care.

###### Endovascular Intervention Versus Exercise Training

Claudication onset measures were reported in five studies: ICD (three studies), PFWD (one), and COT (one). A random-effects meta-analysis included four of these studies (one good quality, three fair)16,74,80,82 reporting ICD or PFWD. In the study reporting COT change at 6 months,77 mean change from baseline in the endovascular group was 3.6 sec (SD 4.2) and the exercise group was 3.0 sec (SD 2.9), p=NS. Our calculated effect size of endovascular intervention compared to exercise was 0.18 (SE 0.23), which means there was a small, nonsignificant effect favoring endovascular treatment.

###### Surgical Revascularization Versus Exercise Plus Medical Therapy

One study reported COT.67 COT (minutes) improved from 2.8 (SD 0.3) to 7.3 (SD 0.9) in the exercise plus medical therapy (pentoxifylline) arm and from 1.4 (SD 0.5) to >10 in the surgical revascularization arm. We were unable to compute an effect size since the 12-week result in the surgical arm was a categorical (nonexact) value and the authors did not report an exact p-value.

###### Endovascular Intervention Versus Surgical Revascularization

No study reported measures of claudication onset distance for this comparison.

##### Analysis of Claudication Onset Measures

Table 17 presents the 21 studies that reported claudication onset measures ICD, PFWD, PFWT, or COT, organized alphabetically by study comparison. Of these studies, 12 were included in the random-effects network meta-analysis (Figure 16).

We conducted a random-effects network meta-analysis with 12 studies16,25,68,71,73,74,80,82,86,93,95,96 to compare the multiple treatment arms on continuous measures (PROC NLMIXED). The results show summary effect sizes of 0.63 (95% CI, -0.02 to 1.29, p=0.059) for cilostazol; 0.69 (CI, 0.23 to 1.15, p=0.003) for exercise training; and 0.79 (CI, 0.29 to 1.29, p=0.002) for endovascular intervention compared with usual care. These effects are summarized in Figure 16. Note that the three treatments are not significantly different from each other, with effect sizes ranging from 0.06 to 0.16 (no effect to small effect).

Thus, cilostazol, exercise training, and endovascular interventions had a medium effect compared with usual care. Clinically, this equates to an improvement in ICD or PFWD of 35 meters for cilostazol, 39 meters for exercise training, and 44 meters for endovascular intervention. There was no effect seen between exercise training and cilostazol (ES=0.06) and small effects seen between endovascular intervention compared with cilostazol (ES=0.16) and exercise (ES=0.10), both favoring endovascular intervention. The overall SOE was rated low for all six comparisons.

##### Effect on Quality-of-Life Measures

We identified 13 unique studies that reported measures quality of life, such as the SF-36, WIQ, EQ-5D, VascuQOL, or PAQ. Results by study comparison are listed in Table 18. There was significant heterogeneity in the study protocols and data reporting.

Table 18 Calculated effect size: quality-of-life measures

Study | Type of Study N Analyzed^a^ Quality | Outcome Length of Followup | Results Reported by Authors | Calculated Effect Size^b^
Medical therapy vs. usual care
Beebe, 1999^49^ | RCT N: 419 Good | Mean SF-36 improvement from baseline; 1. Physical function; 2. Role-physical; 3. Bodily pain; Mean WIQ change from baseline:; 1. walking speed; 2. walking distance; 6 mo | SF-36:; 1. Cilostazol 100 BID: 7.1; Cilostazol 50 BID: 8.0; Placebo: 2.0; 2. Cilostazol 100 BID: 5.3; Cilostazol 50 BID: 4.4; Placebo: -2.8; 3. Cilostazol 100 BID: 7.2; Cilostazol 50 BID: 4.6; Placebo: -1.8; WIQ:; 1. Cilostazol 100 BID: 0.1; Cilostazol 50 BID: 0.2; Placebo: 0.1; 2. Cilostazol 100 BID: 0.2; Cilostazol 50 BID: 0.2; Placebo: 0.1 | ES (cilostazol 100): 0.31 EffSE: 0.14 ES (cilostazol 50): 0.36 EffSE: 0.14
Money, 1998^89^ | RCT N: 212 Fair | SF-36 physical score 4 mo | Score Improvement: Cilostazol: 20% Placebo: 0% | ES (cilostazol): 0.36 EffSE: 0.13
Exercise training vs. usual care
Gardner, 2002^68^ | RCT N at 6 mo: 40 N at 18 mo: 31 Fair | 1. WIQ distance; 2. WIQ speed; 3. WIQ stair climbing; 18 mo; 4 SF36 QOL physical composite score; 5 SF36 QOL mental health composite score; 6 mo | Percent change in score; 1. Supervised exercise 21%, usual care 3%; 2. Supervised exercise 34%, usual care 6%; 3. Supervised exercise 24%, usual care 15%; Mean SF-36 QOL (SD); 4 Supervised exercise baseline: 41 (2); 6 mo: 41(2); Usual care baseline: 40 (3); 6 mo: 39 (2); 5 Supervised exercise baseline: 55 (3); 6 mo: 59 (2); Usual care baseline: 53(3); 6 mo: 53 (3) | ES: 0.16 EffSE: 0.32
Gardner, 2011^69^ | RCT N: 63 Good | 1. SF-36 physical function; 2. WIQ distance; 3. WIQ speed; 4. WIQ stair climbing; 12 wk | Mean change score (SD); 1. Supervised exercise 9 (16), usual care -1 (17), home exercise 8 (15); 2. Supervised exercise 13 (28), usual care 8 (20), home exercise 10 (25); 3. Supervised exercise 9(15), usual care 4 (25), home exercise 11 (22); 4. Supervised exercise 12 (15), usual care 3 (25), home exercise 10 (22) | ES: 0.60 EffSE: 0.26
Lee, 2007^75^ | Observational N: 70 Poor | SF-36; 1. Physical function; 2. Role limited; 3. Bodily pain; 4. General health; 5. Vitality; 6 mo | Median SF-36 score (IQR); 1. Exercise: baseline 45.0 (25 to 62.5); 6 mo 50 (35 to 67.5); Usual care: baseline 52.5 (45 to 70); 6 mo 37.5 (11.3 to 63.8); 2. Exercise: baseline 0 (0 to 75); 6 mo 25 (0 to 87.5); Usual care: baseline 25 (0 to 100); 6 mo 0 (0 to 100); 3. Exercise: baseline 52 (42 to 69); 6 mo 42 (31 to 52); Usual care: baseline 31 (22 to 60); 6 mo 32 (22 to 52); 4. Exercise: baseline 65 (52 to 72); 6 mo 60 (47 to 52.5); Usual care: baseline 52 (40 to 60); 6 mo 47.5 (31.2 to 67); 5. Exercise: baseline 55 (50 to 70); 6 mo 55 (50 to 60); Usual care: baseline 55 (40 to 62); 6 mo 45 (32.5 to 57.5) | ES: 0.08 EffSE: 0.24
Murphy, 2012^77^ CLEVER Study | RCT N: 58 Good | 1. SF12 physical; 2. WIQ walking distance; 3. WIQ pain severity; 4. WIQ walking speed; 5. WIQ stair climbing; 6. PAQ summary; 6 mo | Mean change from baseline (SD); 1. Exercise 5.9 (10.1); Usual care 1.2 (11.0); 2. Exercise 25.1 (27.6); Usual care 0.5 (26.0); 3. Exercise 26.3 (36.3); Usual care 16.3 (34.7); 4. Exercise 16.5 (19.7); Usual care 1.47 (15.69); 5. Exercise 24.0 (10.9); Usual care 10.2 (29.3); 6. Exercise 13.8 (17.0); Usual care -3.1 (18.6) | ES: 0.61 EffSE: 0.17
Tsai, 2002^79^ | RCT N: 53 Poor | SF-36; 1. Physical function; 2. Role limitation; 3. Bodily pain; 3 mo | Mean SF-36 Score (SD); 1. Exercise: baseline 39.5 (11.0); 3 mo 58.0 (10.6); Control: baseline 49.2 (11.2); 3 mo 48.0 (9.6); 2. Exercise: baseline 22.5 (30.0); 3 mo 62.5 (31.7),; Control: baseline 22.9 (19.8); 3 mo 33.3 (16.3); 3. Exercise: baseline 64.8 (15.9); 3 mo 81.5 (18.4); Control: baseline 71.1 (20.4); 3 mo 77.3 (17.8) | ES: 1.79 EffSE: 0.21
Endovascular intervention vs. usual care
Feinglass, 2000^91^ | Observational N: 321 Fair | 1. WIQ walking distance; 2. SF-36 bodily pain; 18 mo | Effect Size; 1. Endovascular 0.98, usual care -0.11; 2. Endovascular 0.2, usual care -0.11 | Not calculated
Murphy, 2012^77^ CLEVER Study | RCT N: 61 Good | 1. SF12 physical; 2. WIQ walking distance; 3. WIQ pain severity; 4. WIQ walking speed; 5. WIQ stair climbing; 6. PAQ summary; 6 mo | Mean change from baseline (SD); 1. Usual care 1.2 (11.0), Endovascular therapy 6.6 (8.5); 2. Usual care 0.5 (26.0), Endovascular therapy 43.8 (42.2); 3. Usual care 16.3 (34.7), endovascular therapy 40.4 (43.9); 4. Usual care 1.47 (15.69), Endovascular therapy 30.8 (31.0); 5. Usual care 10.2 (29.3), Endovascular therapy 29.3 (39.1); 6. Usual care -3.1 (18.6), Endovascular therapy 28.0 (26.4) | ES: 0.69 EffSE: 0.14
Nylaende, 2007^93^ OBACT Study | RCT N: 56 Good | SF-36 physical function 24 mo | Mean change in SF-36 Physical Functioning Score (SD) Endovascular 0.11 (0.32), usual care -0.06 (0.26) | ES: 0.13 EffSE: 0.21
Pell, 1997^94^ | Observational N: 138 Fair | SF-36; 1. Physical function; 2. Role limited; 3. Bodily pain; 4. General Health; 5. Vitality; 6 mo | Mean change (SE); 1. Endovascular 10.8 (6), usual care -0.7 (2.2); 2. Endovascular 18.1 (10), usual care -10.7 (3.8); 3. Endovascular 12.3 (5.3), usual care -3.3 (2.1); 4. Endovascular -1.3 (5.3), usual care -8.2 (2.3); 5. Endovascular 0 (5.1), usual care -9.7 (2.4) | ES: 0.77 EffSE: 0.25
Endovascular intervention vs. exercise training
Greenhalgh, 2008^80^ MIMIC Study | RCT N: 94 Fair | SF-36 physical function score 24 mo | Mean score (SD) [underlined: Femoropopliteal group] Baseline: Exercise 39.7 (7.4), endovascular 38.9 (8.5) 24 mo: Exercise 39.2, endovascular 40.9 [underlined: Aortoiliac group] Baseline: Exercise 37.7 (8.2), endovascular 38.3 (9.0) 24 mo: Exercise 38.6, endovascular 46.4 | ES (femor): -0.02 EffSE: 0.11 ES (aortoiliac): 0.49 EffSE: 0.20
Mazari, 2012^82^ | RCT N: 109 Good | SF-36; 1. Physical function; 2. Role limited; 3. Bodily pain; 4. General health; 5. Vitality; VascuQOL 12 mo | Median score (IQR); 1. Baseline: Endovascular 35 (25 to 45), exercise 35 (20 to 53); 12 mo: Endovascular 47.5 (28.69 to 80), exercise 47.5 (28.75 to 76.25); 2. Baseline: Endovascular 0 (0 to 75), exercise 18.75 (0 to 50) 12 mo: Endovascular 25 (0 to 100), exercise 25 (0 to 100); 3. Baseline: Endovascular 41 (22 to 72), exercise 41 (31 to 68.5); 12 mo: Endovascular 57.5 (34.25 to 78.5), exercise 52 (41 to 72.5); 4. Baseline: Endovascular 57 (35 to 72), exercise 55 (37.75 to 64.25); 12 mo: Endovascular 55 (35 to 77), exercise 57 (37.5 to 72); 5. Baseline: Endovascular 45 (35, 65), exercise 47.5 (35 to 65); VascuQOL Baseline: Endovascular 3.88 (3.16 to 5.0), exercise 4.16 (3.02 to 5.12) 12 mo: 5.29 (3.82 to 6.46), exercise 5.14 (3.96 to 6.08) | ES (endo): 0.62 EffSE: 0.14 ES (ex): 0.47 EffSE: 0.12
Murphy, 2012^77^ CLEVER Study | RCT N: 79 Good | 1. SF12 physical; 2. WIQ walking distance; 3. WIQ pain severity; 4. WIQ walking speed; 5. WIQ stair climbing; 6. PAQ summary; 6 mo | Mean change from baseline (SD); 1. Exercise 5.9 (10.1), Usual care 1.2 (11.0),; Endovascular therapy 6.6 (8.5); 2. Exercise 25.1 (27.6), Usual care 0.5 (26.0),; Endovascular therapy 43.8 (42.2); 3. Exercise 26.3 (36.3), Usual care 16.3 (34.7),; endovascular therapy 40.4 (43.9); 4. Exercise 16.5 (19.7), Usual care 1.47 (15.69),; Endovascular therapy 30.8 (31.0); 5. Exercise 24.0 (10.9), Usual care 10.2 (29.3),; Endovascular therapy 29.3 (39.1); 6. Exercise 13.8 (17.0), Usual care -3.1 (18.6),; Endovascular therapy 28.0 (26.4) | ES (endo): 0.69 EffSE: 0.14 ES (ex): 0.61 EffSE: 0.17
Spronk, 2009^16^ | RCT N: 150 Fair | SF-36; 1. Physical score; 2. Role limitation; 3. Bodily pain; 4. General health; VascuQOL EQ-5D 12 mo | Adjusted mean change (99% CI); 1. Endovascular 17 (12, 22), exercise 13 (8, 18); 2. Endovascular 21 (10, 32), exercise 6 (-4, 16); 3. Endovascular 11 (5, 17), exercise 10 (4, 16); 4. Endovascular 2 (-3, 7), exercise 5 (1,9); VascuQOL: endovascular 0.7 (0.3 to 1.1), exercise 0.6 (0.3, 0.9) EQ-5D score: endovascular 0.11 (0.04, 0.18), exercise 0.07 (0.02, 0.13) | ES (endo): 1.01 EffSE: 0.12 ES (ex): 0.77 EffSE: 0.12
Endovascular intervention vs. surgical revascularization
Feinglass, 2000^91^ | Observational N: 104 Fair | SF-36 18 mo | Mean change (SD) Medication -2 (19) Matched medication 3 (23) Surgical 17 (26) Endovascular 14 (21) | ES: 0.12 EffSE: 0.20
Pell, 1997^94^ | Observational N: 138 Fair | SF-36; 1. Physical functioning; 2. Physical role; 3. Bodily pain; 4. General health; 5. Vitality; 6 mo | Mean (SD); 1. Conservative management 42.5 (2.1), endovascular 42.4 (5.3), surgical 32.9 (4.6); 2. Conservative management 39.9 (3.9), endovascular 44.4 (10.0), surgical 27.8 (9.9); 3. Conservative management 48.3 (2.1), endovascular 46.5 (4.8), surgical 43.3 (6.4); 4. Conservative management 57.1 (1.4), endovascular 56.7 (2.4), surgical 53.9 (3.4); 5. Conservative management 54.6 (1.9), endovascular 37.4 (5.6), surgical 51.3 (4.3) | ES: 0.14 EffSE: 0.33

a Number of patients in the study arms of interest.

b Values used in meta-analysis of RCTs appear in bold.

Abbreviations: BID=two times a day; EffSE=standard error of effect; ES=effect size; IQR=interquartile range; m=meters; min=minute/minutes; mo=month/months; RCT=randomized controlled trial; SD=standard deviation; SF-36=short-form (36) health survey; WIQ=walking impairment questionnaire; wk=week/weeks.

###### Medical Therapy Versus Usual Care

Two studies (1 good quality, 1 fair) reported SF-36 as a measure of quality of life and were included in the random-effects meta-analysis.49,89 None of these studies reported EQ-5D, VascuQOL, PAQ, or WIQ.

###### Exercise Training Versus Usual Care

Five studies (two good quality, one fair, two poor) reported SF-36 as a measure of quality of life, and three reported WIQ. A random-effects meta-analysis included all of these studies68,69,75,77,79 examining the difference in SF-36 measure of physical functioning between exercise and usual care.

###### Endovascular Intervention Versus Usual Care

Five studies reported SF-36 as a measure of quality of life, and no studies reported EQ-5D, VascuQOL, PAQ, or WIQ. The random-effects meta-analysis included two RCTs (two good quality)77,93 but not the two prospective observational studies (both fair)91,94 reporting SF-36 physical functioning.

###### Endovascular Intervention Versus Exercise Training

Four studies reported SF-36 as a measure of quality of life, one reported EQ-5D, one reported VascuQOL, one reported PAQ, and one reported WIQ. The random-effects meta-analysis included all four studies (two good quality, two fair)16,77,80,82 reporting SF-36 physical functioning scores.

###### Endovascular Intervention Versus Surgical Revascularization

Two studies included in the random-effects meta-analysis reported SF-36 as a measure of quality of life,91,94 and no studies reported EQ-5D, VascuQOL, PAQ, or WIQ.

##### Analysis of Quality-of-Life Measures

Table 18 presents the 13 studies that reported measures of quality of life, organized alphabetically by study comparison. Of these studies, ten were included in the random-effects network meta-analyses (Figures 17 and 18).

Figure 17 Network meta-analysis of treatment effects versus usual care on quality of life in IC patients

Abbreviation: CI=confidence interval.

This figure displays a forest plot of 10 studies examining the effect of treatments compared with usual care on quality of life measures in IC patients. The results show summary effect sizes of 0.44 (95% CI, 0.05 to 0.83, p=0.0278) favoring cilostazol; 0.56 (CI, 0.26 to 0.87, p=0.0003) favoring exercise; 0.61 (CI, 0.30 to 0.93, p=0.0001) favoring endovascular; and 0.82 (CI, 0.26 to 1.39, p=0.0044) favoring surgical.

Figure 18 Network meta-analysis of treatment effects versus each other on quality of life in IC patients

Abbreviation: CI=confidence interval.

This figure shows the forest plot of 10 studies examining the effect of treatments compared with each other on quality of life measures in IC patients. The effect size for cilostazol versus exercise training was 0.12 (95% CI, -0.32 to 0.56), favoring exercise training. The effect size for cilostazol versus endovascular was 0.17 (CI, -0.27 to 0.62), favoring endovascular. The effect size for cilostazol versus surgical was 0.38 (CI, -0.27 to 1.03), favoring surgical. The effect size for exercise training versus endovascular was 0.05 (CI, -0.24 to 0.34), showing no effect. The effect size for exercise training versus surgical was 0.26 (CI, -0.31 to 0.83), favoring surgical. The effect size for endovascular versus surgical was 0.21 (CI, -0.34 to 0.76), favoring surgical.

We conducted a random-effects meta-analysis with 10 studies16,49,68,69,77,79,80,82,89,91,93,94 to compare the multiple treatment arms on continuous measures (PROC NLMIXED). Results showed summary effect sizes that were statistically significant compared to usual care for cilostazol (2 studies; p=0.0278), exercise training (7 studies; p=0.0003), endovascular intervention (6 studies; p=0.0001), and surgical revascularization (2 studies; p=0.0044). The results comparing active treatments with each other were not significantly different. These effects are summarized in Figures 17 and 18. We also ran a sensitivity analysis without the three observational studies,75,91,94 and the summary effect sizes for cilostazol, exercise training, and endovascular interventions were similar and still significantly better than usual care. Note that removing the Feinglass and Pell observational studies also removes the surgical versus endovascular and surgical versus usual care indirect comparison. Therefore, the full analysis combining RCTs and observational studies is presented below.

Thus, when compared with usual care, cilostazol and exercise training had moderate effects on physical functioning, while endovascular and surgical interventions had large effects (Figure 17). Clinically, this equates to an improvement in SF-36 physical functioning domain score of 4.4 for cilostazol, 5.6 for exercise training, 6.1 for endovascular intervention, and 8.3 for surgical intervention. Figure 18 shows that the effect sizes comparing cilostazol, exercise training, endovascular intervention, and surgical intervention were negligible or small, ranging from 0.05 to 0.38. The overall SOE was rated low for all comparisons on the basis consistent results of an indirect analysis with a wide confidence interval.

##### Effect on Other Outcome Measures

We identified six studies that reported other outcome measures, such as amputation, repeat revascularization, vessel patency, wound healing, bleeding, and analog pain scale.

###### Medical Therapy Versus Usual Care

Amputation was measured in two studies49,51 and occurred in only one patient (treated with usual care). Revascularization was measured in the same two studies and occurred more frequently in patients treated with usual care (10.5%) compared with medical therapy (3.6%). Vessel patency, wound healing and analog pain scale were not measured in any of the studies for this comparison.

###### Exercise Training Versus Usual Care

Amputation was measured in a single study68 and occurred in only one patient (treated with exercise). Vessel patency was measured in a single study;70 however, it was only measured in the endovascular and surgical revascularization groups (results reported under endovascular versus usual care section) and not in the exercise or control groups. Repeat revascularization, wound healing, analog pain scale, bleeding, and amputation were not measured in any of the studies for this comparison.

###### Endovascular Intervention Versus Usual Care

Amputation was measured in two studies with a range of followup between 1 and 2 years70,91 with amputation occurring in similar proportions in patients treated with endovascular revascularization and usual care (Gelin study: 2% usual care, 1% endovascular; Feinglass study: two in medical therapy arm, three in endovascular arm). Vessel patency was reported in a single study,70 and only patients receiving revascularization procedures had vessel patency outcomes reported (endovascular group 59%, surgical group 98%). Repeat revascularization, wound healing, analog pain scale, and bleeding were not measured in any of the studies for this comparison.

###### Surgical Revascularization Versus Usual Care

Vessel patency was measured in a single study;76 however, it was measured only in the surgical revascularization group and not in the usual care group. Amputation, repeat revascularization, wound healing, analog pain scale, and bleeding were not measured in any of the studies for this comparison.

###### Endovascular Intervention Versus Exercise Training

Vessel patency and amputation were each measured in a single study.70 Vessel patency was not reported in the exercise group. Amputation occurred in one patient in the endovascular group and in none of the patients in the exercise group. Repeat revascularization, wound healing, analog pain scale, and bleeding were not measured in any of the studies for this comparison.

###### Endovascular Intervention Versus Surgical Revascularization

Vessel patency, repeat revascularization, amputation, wound healing, analog pain scale, and bleeding were not measured in any of the studies for this comparison.

#### Modifiers of Effectiveness

Table 19 summarizes the six studies—four RCTs (two good quality, two fair) and two observational studies (one fair, one poor)—that reported variations in treatment effectiveness by subgroup, arranged alphabetically. Two studies compared medical therapy with usual care,51,86 one study compared endovascular revascularization with exercise training,84 and two studies compared endovascular revascularization or surgical revascularization and with usual care.70,76,91 Despite limited data to draw definitive conclusions, one study reported improvements in quality-of-life measures and ABI in patients with successful endovascular revascularization when compared with patients without successful endovascular revascularization. One other study reported a statistically nonsignificant improvement in MWD favoring exercise training over endovascular revascularization in patients with SFA stenosis when compared with patients with iliac stenosis.

Table 19 Studies reporting subgroup results (modifiers of effectiveness) in the IC population

Study | Type of Study N Analyzed^a^ Comparison Quality | Subgroup | Results Reported by Authors
Dawson, 1998^86^ | RCT N: 81 Cilostazol vs. placebo Good | On treatment analysis (limited to those completing 12 wk of therapy) | Percent change in walking distances from baseline (geometric mean) Cilostazol (N=44): 31% Placebo (N=22): -4.6%
Feinglass, 2000^91^ | Observational N: 526 Endovascular revascularization vs. medical therapy Fair | Success of revascularization technique only on the revascularization group | QOL Bypass grafting ABI change >0.1 (mean [SD]) (N=37); 1. SF-36 physical functioning score 28 (23); 2. WIQ walking distance score 0.43 (0.27); 3. SF36 bodily pain score 25 (24); 4. ABI 0.36 (0.15); Bypass grafting ABI change <0.1 (mean [SD]) (N=23); 1. SF36 physical functioning score -0.8 (18); 2. WIQ walking distance score 0.01 (0.23); 3. SF36 bodily pain score 5 (24); 4. ABI -0.01 (0.12); Angioplasty ABI change >0.1 (mean [SD]) (N=22); 1. SF-36 physical functioning score 20 (23); 2. WIQ walking distance score 0.35 (0.28); 3. SF36 bodily pain score 12 (24); 4. ABI 0.23 (0.11); Angioplasty ABI change <0.1 (mean [SD]) (N=22); 1. SF-36 physical functioning score 7 (17); 2. WIQ walking distance score 0.20 (0.26); 3. SF-36 bodily pain score 13 (18); 4. ABI -0.01 (0.01)
Gelin, 2001^70^ | RCT N: 264 Supervised exercise vs. invasive therapy (surgical or endovascular) vs. control Fair | Suprainguinal vs. infrainguinal reconstructions | 1-yr patency Suprainguinal 89% (24 of 27) Infrainguinal 76% (26 of 34) p-value not provided by author; our calculated p-value=0.21
Mori, 2002^76^ | Observational N: 427 Surgical revascularization vs. usual care Poor | Suprainguinal patency; 1. Aortofemoral bypass; 2. Axillofemoral bypass; 3. Femorofemoral bypass | Suprainguinal patency; 1. 95.1%; 2. 95.5%; 3. 83.3%
Mori, 2002^76^ | Observational N: 427 Surgical revascularization vs. usual care Poor | Infrainguinal patency; 1. Above knee femoropopliteal bypass; 2. Below knee femoropopliteal bypass | Infrainguinal patency; 1. 67.6%; 2. 45.2%
Mori, 2002^76^ | Observational N: 427 Surgical revascularization vs. usual care Poor | Above knee bypass; 1. Synthetic graft; 2. Auto vein graft | Above knee bypass; 1. 64.2%; 2. 85.7%
Mori, 2002^76^ | Observational N: 427 Surgical revascularization vs. usual care Poor | Below knee bypass; 1. Synthetic graft; 2. Auto vein graft | Below knee bypass; 1. 38.9%; 2. 57.1%
Mori, 2002^76^ | Observational N: 427 Surgical revascularization vs. usual care Poor | 5 yr
Perkins, 1996^84^ | RCT N: 56 Endovascular revascularization vs. supervised exercise Fair | Iliac stenosis vs. superficial femoral stenosis in exercise vs. PTA | Median MWD at 15 mo (SE) SFA stenosis: PTA (N=15) 161.43 (66), exercise (N=13) 723.8 (124.7) Iliac stenosis: PTA (N=15) 171.3 (125.8), exercise (N=13) 374.3 (96)
Soga, 2009^51^ | RCT N: 78 Cilostazol vs. placebo Good | Occlusive vs. nonocclusive disease | Repeat revascularization Occlusive disease: Cilostazol 50% Placebo 36% Nonocclusive disease: Cilostazol 3.4% Placebo 39%

a Number of patients in the study arms of interest.

Abbreviations: ABI=ankle-brachial-index; ACD=absolute claudication distance; ICD=initial claudication distance; MWD=maximal walking distance; PTA=percutaneous transluminal angioplasty; QOL=quality of life; RCT=randomized controlled trial; SD=standard deviation; SE=standard error; SFA=superficial femoral artery; WIQ=Walking Impairment Questionnaire.

We found no studies reporting results by the following subgroups: age, sex, race, presence of diabetes mellitus or renal disease, smoking status, use of exercise or medical therapy prior to invasive management, or prior revascularization. The SOE for modifiers of effectiveness was insufficient given the variation in subgroups that were studied and the outcomes reported.

#### Safety Concerns

Table 20 describes the 17 RCTs (8 good, 8 fair, 1 poor) that reported safety concerns, arranged alphabetically. Ten RCTs measured harm in a comparison of medical therapy and usual care, three RCTs measured harm in a comparison of exercise training and usual care, three RCTs measured harm in a comparison of endovascular revascularization and usual care, and five RCTs measured harm in a comparison of endovascular revascularization and exercise training. Five RCTs reported both headache and diarrhea.25,49,73,89,90 Five RCTs reported serious adverse events,25,85,87,89,90 and three RCTs reported bleeding.51,88,93

Table 20 Studies reporting harms of therapies in the IC population

Study | Type of Study N Analyzed^a^ Comparison Quality | Harm Length of Followup | Results Reported by Authors
Beebe, 1999^49^ | RCT N: 419 Cilostazol 100 mg vs. cilostazol 50 mg vs. placebo Good | 1. Headache; 2. Abnormal stools; 3. Diarrhea; 4. Dizziness; 5. Palpitations; 24 wk | 1. Headache: cilostazol 100 34.3%, cilostazol 50 23.4%, placebo 14.7%; 2. Abnormal stool: cilostazol 100 14.9%, cilostazol 50 14.6%, placebo 3.5%; 3. Diarrhea: cilostazol 100 12%, cilostazol 50 9.9%, placebo 8.7%; 4. Dizziness: cilostazol 100 10.3%, cilostazol 50 8.8%, placebo 4.7%; 5. Palpitations: cilostazol 100 11.4%, cilostazol 50 4.7%, placebo 0%
Belcaro, 2002^85^ | RCT N: 53 Pentoxifylline vs. placebo Fair | Serious side effects 6 mo | Serious side effects: pentoxifylline 0, placebo 0
Dawson, 1998^86^ | RCT N: 77 Cilostazol vs. placebo Good | 1. Hospitalizations; 2. pneumonia; 12 wk | 1. Cilostazol 6, placebo 0; 2. Cilostazol 2, placebo 0
Dawson, 2000^25^ | RCT N: 698 Cilostazol vs. pentoxifylline vs. placebo Good | 1. Headache; 2. Pain; 3. Diarrhea; 4. Pharyngitis; 5. Peripheral vascular disorder; 6. Abnormal stools; 7. Palpitation; 8. Serious adverse events; 28 wk | 1. Headache: cilostazol 28%, pentoxifylline 11%, placebo 12%; 2. Pain: cilostazol 13%, pentoxifylline 16%, placebo 14%; 3. Diarrhea: cilostazol 19%, pentoxifylline 8%, placebo 5%; 4. Pharyngitis: cilostazol 10%, pentoxifylline 14%, placebo 7%; 5. Peripheral vascular disorder: cilostazol 6%, pentoxifylline 10%, placebo 11%; 6. Abnormal stools: cilostazol 15%, pentoxifylline 5%, placebo 3%; 7. Palpitation: cilostazol 17%, pentoxifylline 2%, placebo 1%; 8. Serious adverse events: cilostazol 12%, pentoxifylline 13%, placebo 13%
De Sanctis, 2002^98^ | RCT N: 135 Pentoxifylline vs. placebo Fair | Side effects 12 mo | Side effects: pentoxifylline 0, placebo 0
De Sanctis, 2002^87^ | RCT N: 101 Pentoxifylline vs. placebo Poor | Serious side effects | Serious Side Effects: pentoxifylline 0, placebo 0
Gardner, 2002^68^ | RCT N: 31 Supervised exercise vs. control Fair | Side effects 18 mo | Supervised exercise: 0, usual care: 0
Greenhalgh, 2008^80^ | RCT N: 106 Supervised exercise + best medical therapy vs. supervised exercise + best medical therapy + PTA Fair | 1. Minor hematomas; 2. Dissected artery; 3. Sensory deficit; 24 mo | 1. Minor hematomas: supervised exercise + best medical therapy + PTA 8, supervised exercise + best medical therapy 0; 2. Dissected artery: supervised exercise + best medical therapy + PTA 1, supervised exercise + best medical therapy 0; 3. Sensory deficit: supervised exercise + best medical therapy + PTA 8, supervised exercise + best medical therapy 0
Hiatt, 2008^88^ | RCT N: 1435 Cilostazol vs. placebo Good | 1. Dyspnea; 2. Serious bleeding; 36 mo | 1. Dyspnea: cilostazol 7 (1%), placebo 3 (0.4%); 2. Serious bleeding: cilostazol 18 (2.5%), placebo 22 (3.1%)
Hobbs, 2007^73^ | RCT N: 34 Medical therapy + supervised exercise vs. medical therapy + cilostazol vs medical therapy + supervised exercise + cilostazol Good | 1. Headache; 2. Diarrhea; 6 mo | 1. Headache: patients taking cilostazol 2, medical therapy 0; 2. Diarrhea: patients taking cilostazol 3, medical therapy 0
Money, 1998^89^ | RCT N: 212 Cilostazol vs. placebo Fair | 1. Headache; 2. Abnormal stools; 3. Diarrhea; 4. Dizziness; 5. Serious adverse events; 16 wk | 1. Headache: cilostazol 30.3%, placebo 9.2%; 2. Abnormal stool: cilostazol 16%, placebo 5.0%; 3. Diarrhea: cilostazol 12.6%, placebo 6.7%; 4. Dizziness: cilostazol 12.6%, placebo 5.0%; 5. Serious adverse events: cilostazol 11.8%, placebo 9.2%
Murphy, 2012^77^ | RCT N: 99 Supervised exercise vs. primary stenting vs. optimal medical care for IC Good | 1. Transfusion; 2. Arterial dissection; 3. Arterial perforation; 6 mo | 1. Transfusion: PTA 1, supervised exercise 0, optimal medical therapy 0; 2. Arterial dissection: PTA 2, supervised exercise 0, optimal medical therapy 0; 3. Arterial perforation PTA 1, supervised exercise 0, optimal medical therapy 0
Nylaende, 2007^93^ | RCT N: 56 Optimal medical therapy vs. PTA + optimal medical therapy Good | 1. Bleeding; 2. Emboli; 3. Local thrombosis; 4. Arterial dissection / perforation; 5. Hematoma requiring surgical management; 24 mo | 1. Bleeding: PTA + optimal medical therapy 0, optimal medical therapy 0; 2. Emboli: PTA + optimal medical therapy 0, optimal medical therapy 0; 3. Local thrombosis: PTA + optimal medical therapy 0, optimal medical therapy 0; 4. Arterial dissection / perforation: PTA + optimal medical therapy 0, optimal medical therapy 0; 5. Hematoma requiring surgical management: PTA + optimal medical therapy 0, optimal medical therapy 0
Perkins, 1996^84^ | RCT N: 56 Exercise vs. PTA Fair | 1. Contralateral angioplasty; 2. Surgery; 6 yr | 1. Contralateral angioplasty: exercise 3/26, PTA 3/30; 2. Surgery: exercise 2/26, PTA 2/30
Soga, 2009^51^ | RCT N: 78 Cilostazol vs. control Good | 1. Major bleeding; 2. Palpitations; 24 mo | 1. Major bleeding: cilostazol 0/39, control 0/39; 2. Palpitations: cilostazol 2/39, control 0/39
Spronk, 2009^16^ | RCT N: 150 PTA vs. exercise Fair | 1. Minor complications; 2. Hematoma; 3. Dissection; 12 mo | 1. Minor complications: PTA 7/75, exercise 0/75; 2. Hematoma: PTA 6/75, exercise 0/75; 3. Arterial dissection: PTA 1/75, exercise 0/75
Strandness, 2002^90^ | RCT N: 394 Cilostazol vs. placebo Fair | 1. Abnormal stools; 2. Serious adverse event; 3. Headache; 4. Infection; 5. Pain; 6. Diarrhea; 24 wk | 1. Abnormal stools: cilostazol 100 19.5%, cilostazol 50 6.1%, placebo 5.4%; 2. Serious adverse event: cilostazol 100 18.8%, cilostazol 50 16.7%, placebo 15.5%; 3. Headache: cilostazol 100 40.6%, cilostazol 50 26.5%, placebo 12.4%; 4. Infection: cilostazol 100 18%, cilostazol 50 17.4%, placebo 12.4%; 5. Pain: cilostazol 100 11.3%, cilostazol 50 19.7%, placebo 14.0%; 6. Diarrhea: cilostazol 100 16.5%, cilostazol 50 10.6%, placebo 6.2%

a Number of patients in the study arms of interest.

Abbreviations: ABI=ankle-brachial-index; ACD=absolute claudication distance; ICD=initial claudication distance; mo=month/months; PTA=percutaneous transluminal angioplasty; RCT=randomized controlled trial; SFA=superficial femoral artery; wk=week/weeks.

Figure 19 shows the forest plot for the random-effects meta-analysis of the five RCTs comparing cilostazol with placebo and reporting headache as a side effect. The result is an estimated odds ratio of 3.00 (95% CI, 2.29 to 3.95) favoring placebo. There was no evidence of heterogeneity, with a Q-value of 2.46 for 4 degrees of freedom, p=0.65; I^2^=0.00.

Figure 19 Forest plot for meta-analysis of cilostazol versus placebo on headache complications in the IC population

Abbreviation: CI=confidence interval.

This figure shows the forest plot for the random-effects meta-analysis of the five studies comparing cilostazol with placebo and reporting headache as a side effect. The result is an estimated odds ratio of 3.00 (95% CI, 2.29 to 3.95, p=0.0000) favoring placebo.

Figure 20 shows the forest plot for the random-effects meta-analysis of the five RCTs comparing cilostazol with placebo and reporting diarrhea as a side effect. The result is an estimated odds ratio of 2.51 (95% CI, 1.58 to 3.97) favoring placebo. There was no evidence of heterogeneity, with a Q-value of 5.85 for 4 degrees of freedom, p=0.21; I^2^=31.61.

Figure 20 Forest plot for meta-analysis of cilostazol vs. placebo on diarrhea complications in the IC population

Abbreviations: CI=confidence interval.

This figure shows the forest plot for the random-effects meta-analysis of the five studies comparing cilostazol with placebo and reporting diarrhea as a side effect. The result is an estimated odds ratio of 2.51 (95% CI, 1.58 to 3.97, p=0.0001) favoring placebo.

Figure 21 shows the forest plot for the random-effects meta-analysis of the three RCTs comparing cilostazol with placebo and reporting palpitation as a side effect. The result is an estimated odds ratio of 18.11 (95% CI, 5.95 to 55.13) favoring placebo. There was no evidence of heterogeneity, with a Q-value of 0.78 for 2 degrees of freedom, p=0.68; I^2^=0.00.

Figure 21 Forest plot for meta-analysis of cilostazol versus placebo on palpitation complications in the IC population

Abbreviation: CI=confidence interval.

This figure shows the forest plot for the random-effects meta-analysis of the three studies comparing cilostazol with placebo and reporting palpitation as a side effect. The result is an estimated odds ratio of 18.11 (95% CI, 5.95 to 55.13, p=0.00) favoring placebo.

Cilostazol increases the rate of headache (high SOE), diarrhea (moderate SOE) and palpitations (moderate SOE). No studies were identified that measured contrast nephropathy, radiation, infection, or exercise-related harms. No studies reported on whether any of the harms vary by subgroup (age, sex, race, risk factors, comorbidities, anatomic location of disease.

### SOE Ratings for KQ 2

Table 21 summarizes the SOE for the outcomes outlined in KQ 2 by each treatment comparison. We found very few studies that assessed amputation, vessel patency, subgroup differences, or cardiovascular outcomes (all-cause or cardiovascular mortality, nonfatal stroke, nonfatal MI, or composite events); therefore, the evidence base is insufficient for us to draw any conclusions on these outcomes.

Table 21 Detailed SOE for IC therapies by comparator

Comparator | Number of Studies/Design (Total Patients) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect Effect Estimate (95% CI)
All-cause mortality
Medical therapy vs. usual care | 4 RCT (2732) | 3 low risk, 1 moderate risk | Inconsistent | Direct | Imprecise | OR 0.91 (0.62 to 1.35) No difference Low SOE
Exercise vs. usual care | 2 RCT (238) | 1 low risk, 1 moderate risk | Inconsistent | Direct | Imprecise | OR 0.84 (0.34 to 2.07) No difference Low SOE
Endovascular vs. usual care | 2 RCT, 3 observational (977) | 1 low risk, 4 moderate risk | Inconsistent | Direct | Imprecise | OR 0.91 (0.34 to 2.45) No difference Low SOE
Surgical vs. usual care | 1 observational (427) | 1 high risk | NA | Direct | Not reported | 10.4% in surgical group, 16.7% in usual care group Insufficient SOE
Endovascular vs. exercise | 5 RCT (710) | 1 low risk, 4 moderate risk | Inconsistent | Direct | Imprecise | OR 0.77 (0.39 to 1.54) No difference Low SOE
Endovascular vs. surgical | 2 observational (305) | 2 moderate risk | Inconsistent | Direct | Not reported | Results not reported by treatment group; overall mortality rate ranged from 3 to 8% Insufficient SOE
Nonfatal MI
Medical therapy vs. usual care | 2 RCT (497) | 2 low risk | Inconsistent | Direct | Imprecise | Low event rates in both groups Inconclusive Insufficient SOE
Exercise vs. usual care | 1 RCT (63) | 1 low risk | NA | Direct | Not reported | Only one MI total (in exercise group) Insufficient SOE
Endovascular vs. usual care | 1 observational (479) | Moderate risk | NA | Direct | Not reported | 3.0% in endovascular group, 8.8% in usual care group Insufficient SOE
Surgical vs. usual care | 0 | NA | NA | NA | NA | Insufficient SOE
Endovascular vs. exercise | 1 RCT (106) | Moderate risk | NA | Direct | NA | No events occurred in either treatment group Insufficient SOE
Endovascular vs. surgical | 0 | NA | NA | NA | NA | Insufficient SOE
Nonfatal stroke
Medical therapy vs. usual care | 3 RCT (1932) | 3 low risk | Inconsistent | Direct | Imprecise | Low event rates in both groups Inconclusive Insufficient SOE
Exercise vs. usual care | 1 RCT (63) | 1 low risk | NA | Direct | Not reported | 1 stroke in each group Insufficient SOE
Endovascular vs. usual care | 2 observational (800) | 2 moderate risk | NA | Direct | Not reported | One study reported 4 strokes for total study; other study reported 1 stroke in endovascular group, 2 strokes in usual care group Insufficient SOE
Surgical vs. usual care | 0 | NA | NA | NA | NA | Insufficient SOE
Endovascular vs. exercise | 1 RCT (106) | 1 moderate risk | NA | Direct | Not reported | 1 stroke in each group Insufficient SOE
Endovascular vs. surgical | 0 | NA | NA | NA | NA | Insufficient SOE
MWD or ACD
Medical therapy vs. usual care | 6 RCT (cilostazol) (1632) 3 RCT (pentoxifylline) (797) | 3 low risk, 3 moderate risk 2 moderate risk, 1 high risk | Cilostazol Consistent Pentoxifylline Inconsistent | Cilostazol Direct Pentoxifylline Direct | Cilostazol Imprecise Pentoxifylline Imprecise | ES cilostazol: 0.62 (-0.21 to 1.45) full model 0.61 (-0.20 to 1.42) sensitivity analysis No difference Low SOE ES pentoxifylline: 1.70 (0.36 to 3.04) Inconclusive Insufficient SOE
Exercise vs. usual care | 9 RCT, 2 observational (624) | 4 low risk, 4 moderate risk, 3 high risk | Consistent | Direct | Imprecise | ES: 0.89 (0.06 to 1.71) full model 0.98 (0.23 to 1.74) sensitivity analysis Favors exercise Moderate SOE
Endovascular vs. usual care | 4 RCT (285) | 2 low risk, 2 moderate risk | Consistent | Direct | Imprecise | ES: 0.41 (-0.54 to 1.36) full model 0.51 (-0.35 to 1.37) sensitivity analysis No difference Low SOE
Endovascular vs. exercise | 8 RCT (695) | 3 low risk, 5 moderate risk | Consistent | Direct | Imprecise | ES: -0.47 (-1.41 to 0.46) full model -0.47 (-1.31 to 0.36) sensitivity analysis No difference Moderate SOE
Endovascular + exercise vs. usual care | 2 RCT (248) | 2 low risk | Consistent | Direct | Imprecise | ES: 1.08 (-0.37 to 2.53) full model 1.20 (-0.11 to 2.50) sensitivity analysis Favors endovascular intervention + exercise training Low SOE
Surgical vs. exercise + medical therapy (pentoxifylline) | 1 observational (127) | 1 moderate risk | NA | Direct | Imprecise | MWT improved to >15 min in surgical group and >11 min in exercise + medical therapy group Insufficient SOE
Endovascular vs. surgical | 0 | NA | NA | NA | NA | Insufficient SOE
Initial claudication distance or pain-free walking distance
Medical therapy (cilostazol) vs. usual care | 5 RCT (1255) | 3 low risk, 2 moderate risk | Inconsistent | Direct | Imprecise | ES: 0.63 (-0.03 to 1.29) No difference Low SOE
Exercise vs. usual care | 9 RCT, 1 observational (396) | 4 low risk, 4 moderate risk, 2 high risk | Inconsistent | Direct | Imprecise | ES: 0.69 (0.22 to 1.15) Favors exercise Low SOE
Endovascular vs. usual care | 4 RCT, 1 observational (281) | 2 low risk, 2 moderate risk, 1 high risk | Inconsistent | Direct | Imprecise | ES: 0.79 (0.29 to 1.29) Favors endovascular intervention Low SOE
Endovascular vs. exercise | 5 RCT (448) | 2 low risk, 3 moderate risk | Inconsistent | Direct | Imprecise | ES: 0.10 (-0.38 to 0.58) No difference Low SOE
Surgical vs. exercise + medical therapy (pentoxifylline) | 1 observational (127) | 1 moderate risk | NA | Direct | Imprecise | COT improved to >10 min in surgical group and >7 min in exercise + medical therapy group Insufficient SOE
Endovascular vs. surgical | 0 | NA | NA | NA | NA | Insufficient SOE
Quality of life
Medical theray (cilostazol) vs. usual care | 2 RCT (631) | 1 low risk, 1 moderate risk | Consistent | Direct | Imprecise | ES: 0.44 (0.05 to 0.83) Favors cilostazol Low SOE
Exercise vs. usual care | 4 RCT, 1 observational (275) | 2 low risk, 1 moderate risk, 2 high risk | Consistent | Direct | Imprecise | ES: 0.56 (0.26 to 0.87) Favors exercise Low SOE
Endovascular vs. usual care | 2 RCT, 2 observational (576) | 2 low risk, 2 moderate risk | Consistent | Direct | Imprecise | ES: 0.61 (0.30 to 0.93) Favors endovascular intervention Low SOE
Surgical vs. usual care | 2 observational (727) | 2 moderate risk | Consistent | Direct | Imprecise | ES: 0.82 (0.26 to 1.39) Favors surgery Low SOE
Endovascular vs. exercise | 4 RCT (444) | 2 low risk, 2 moderate risk | Consistent | Direct | Imprecise | ES: 0.05 (-0.24 to 0.34) No difference Low SOE
Endovascular vs. surgical | 2 observational (242) | 2 moderate risk | Consistent | Direct | Imprecise | ES: 0.21 (-0.34 to 0.76) No difference Low SOE
Amputation
Medical therapy vs. usual care | 2 RCT (497) | 2 low risk | Inconsistent | Indirect | Imprecise | Only 1 patient underwent amputation Insufficient SOE
Exercise vs. usual care | 1 RCT (31) | 1 moderate risk | NA | Indirect | Not reported | Only 1 patient underwent amputation Insufficient SOE
Endovascular vs. usual care | 1 RCT, 1 observational (473) | 2 moderate risk | Consistent | Indirect | Imprecise | Amputation was similar in endovascular and usual care groups Insufficient SOE
Surgical vs. usual care | 0 | NA | NA | NA | NA | Insufficient SOE
Endovascular vs. exercise | 1 RCT (149) | 1 moderate risk | NA | Indirect | Not reported | One amputation in endovascular group, none in exercise group Insufficient SOE
Endovascular vs. surgical | 0 | NA | NA | NA | NA | Insufficient SOE
Primary patency Secondary patency
Medical therapy vs. usual care | 0 | NA | NA | NA | NA | Insufficient SOE
Exercise vs. invasive vs. usual care (3-arm study) | 1 RCT (225) | 1 moderate risk | NA | Indirect | Not reported | Vessel patency was only reported in patients undergoing revascularization (endovascular group 59%, surgical group 98%) Insufficient SOE
Surgical vs. usual care | 1 observational (427) | 1 high risk | NA | Indirect | Not reported | Vessel patency was only reported in patients undergoing revascularization (aortofemoral bypass 95.5%, axillofemoral bypass 83.3%, femorofemoral bypass 95.5%, femoropopliteal bypass (AK) 67.6%, femorofemoral bypass (BK) 45.2% Insufficient SOE
Endovascular vs. surgical | 0 | NA | NA | NA | NA | Insufficient SOE
Modifiers of effectiveness (subgroups)
Medical therapy vs. usual care | 2 RCT (155) | 2 low risk | NA (reported different outcomes) | Direct | Not reported | Inconclusive evidence due to individual studies reporting different endpoints Insufficient SOE
Endovascular vs. usual care | 1 observational (526) | 1 moderate risk | NA | Indirect | Imprecise | QOL scores were better if ABI improvement was >0.1 after successful revascularization Insufficient SOE
Surgical vs. usual care | 1 observational (427) | 1 high risk | NA | Indirect | Not reported | Patency rates lower for infrainguinal bypass and synthetic graft vs. suprainguinal and autologous vein graft Insufficient SOE
Endovascular vs. exercise | 1 RCT (56) | 1 moderate risk | NA | Indirect | Not reported | Nonsignificant MWD improvement in patients with SFA disease treated with PTA Insufficient SOE
Endovascular vs. surgical | 1 RCT (264) | 1 moderate risk | NA | Indirect | Imprecise | Patency rates similar for suprainguinal and infrainguinal reconstruction Insufficient SOE
Safety concerns
Medical therapy vs. usual care | 10 RCT (3485) | 5 low risk, 4 moderate risk, 1 high risk | Consistent | Direct | Precise for headache; imprecise for diarrhea and palpitations | Higher side effects on cilostazol Headache: OR 3.00 (2.29 to 3.95) High SOE Diarrhea: OR 2.51 (1.58 to 3.97) Moderate SOE Palpitations: OR 18.11 (5.95 to 55.13) Moderate SOE
Exercise vs. usual care | 3 RCT (107) | 2 low risk, 1 moderate risk | Consistent | Indirect | NA | All studies reported no adverse events in exercise or usual care groups Insufficient SOE
Endovascular vs. usual care | 2 RCT (155) | 2 low risk | Inconsistent | Direct | Imprecise | One study reported no events; other study had low rates of transfusion, dissection, and perforation in the endovascular group Insufficient SOE
Endovascular vs. exercise | 5 RCT (282) | 1 low risk, 2 moderate risk | Inconsistent | Indirect | Imprecise | Endovascular interventions were associated with higher rates of transfusion, dissection/perforation, and hematomas Insufficient SOE
Composite cardiovascular events Wound healing Analog pain scale Safety concerns (subgroups)
All | 0 | NA | NA | NA | NA | Insufficient SOE

Abbreviations: ES=effect size; MI=myocardial infarction; MWT=mean walking time; NA=not applicable; OR=odds ratio; QOL=quality of life; RCT=randomized controlled trial; SOE=strength of evidence.

## KQ 3 Comparative Effectiveness and Safety of Usual Care and Endovascular and Surgical Revascularization for CLI

KQ 3. In adults with CLI due to PAD:

a. What is the comparative effectiveness of endovascular intervention (percutaneous transluminal angioplasty, atherectomy, or stents) and surgical revascularization (endarterectomy, bypass surgery) for outcomes including cardiovascular events (e.g., all-cause mortality, myocardial infarction, stroke, cardiovascular death), amputation, quality of life, wound healing, analog pain scale score, functional capacity, repeat revascularization, and vessel patency?
b. Does the effectiveness of treatments vary by subgroup (age, sex, race, risk factors, comorbidities, or anatomic location of disease)?
c. What are the significant safety concerns associated with each treatment strategy (e.g., adverse drug reactions, bleeding, contrast nephropathy, radiation, infection, and periprocedural complications causing acute limb ischemia)? Do the safety concerns vary by subgroup (age, sex, race, risk factors, comorbidities, or anatomic location of disease)?

### Key Points

#### Effectiveness of Interventions

- Four observational studies comparing endovascular interventions with usual care reported on mortality, amputation/limb salvage, amputation-free survival, and hospital length of stay. However, because the results were inconsistent and imprecise, SOE was insufficient.
- All-cause mortality was not different between patients treated with endovascular versus surgical revascularization (low SOE) although endovascular interventions did demonstrate a statistically nonsignificant benefit in all-cause mortality at less than 2 years in the IC-CLI population.
- Amputation-free survival was not different between patients treated with endovascular versus surgical revascularization (low SOE).
- Evidence regarding patency rates varied but secondary patency rates demonstrated a benefit of endovascular interventions compared with surgical revascularization across followup time points (low SOE).

#### Modifiers of Effectiveness

- Seven studies in the CLI population comparing endovascular and surgical interventions, including one RCT and six observational, reported variations in treatment effectiveness by subgroup. Subgroups reported included age (two studies), anatomic factors (two studies), type of vein graft (two studies), and one study each on diabetes and vessel patency. We found no studies reporting results by sex, race, smoking status, or presence of renal disease. The SOE for modifiers of effectiveness was insufficient given the small number of studies and variety of subgroups that were evaluated.
- Seven studies in the mixed IC-CLI comparing endovascular and surgical interventions, including one RCT and six observational, reported variations in treatment effectiveness by subgroup. Subgroups reported include symptom class (three studies), renal failure (two studies), arterial outflow/runoff (two studies), and one study each reporting age, sex, smoking status, presence of hyperlipidemia, coronary artery disease, diabetes mellitus, hypertension, anatomic location of stenosis, and stent graft size. We found no studies reporting results by patency of intervention or type of conduit (autologous vein or prosthetic material). The SOE for modifiers of effectiveness was insufficient given the small number of studies and variety of subgroups that were evaluated.

#### Safety Concerns

- One observational study in the CLI population reported safety concerns. Specifically, this study reported the incidence of thrombosis at 30 days and found that the risk of thrombosis was higher in patients undergoing surgical revascularization than in those undergoing endovascular revascularization. The SOE for harms was insufficient in the studies evaluating patients with CLI given the small number of studies reporting this outcome. It may be that treatment harms are not routinely documented or collected in retrospective or prospective observational studies.
- Six studies (2 RCTs, 4 observational) in the mixed IC-CLI population reported harms of bleeding, infection, renal dysfunction, or periprocedural complications causing acute limb ischemia. There were conflicting results in the summary estimates for periprocedural complications in the IC-CLI population with the observational studies showing lower rates in those who received an endovascular intervention and RCTs showing lower rates in the surgical population; however the wide confidence intervals make the differences nonsignificant (low SOE). Infection was more common in the surgical intervention arm based on three studies (one RCT, two observational; low SOE).

### Description of Included Studies

We identified 37 unique studies (3 RCTs, 34 observational) that evaluated the comparative effectiveness of usual care, endovascular intervention, and surgical revascularization in CLI or IC-CLI patients. Four observational studies compared usual care with endovascular intervention. Of the 37 studies, 23 evaluated the comparative effectiveness of endovascular and surgical revascularization in 12,779 patients with CLI.39,99-120 Of these studies, 1 was an RCT (good quality), and 22 were observational (1 good quality, 11 fair, 10 poor). The clinical outcomes of interest included vessel patency, repeat revascularization, wound healing, analog pain scale score, cardiovascular events (e.g., all-cause mortality, MI, stroke, cardiovascular death), amputation, functional capacity, and quality of life. (Characteristics for each study are presented in Table C-3 in Appendix C.)

Of the 37 studies, 12 evaluated the comparative effectiveness of endovascular and surgical revascularization in a mixed population involving 565,168 PAD patients with either IC or CLI.38,121-131 Of these studies, 2 were RCTs (both rated fair quality) and 10 were observational (4 fair, 6 poor). Similar to KQ 2, a majority of the endovascular procedures consisted of PTA with or without stent placement, and the type of stent was not specified.

The following comparisons were assessed in the included studies and are detailed in this analysis:

1. Endovascular intervention versus usual care (3 observational studies of 562 total patients with CLI and 1 observational study of 107 total patients with either IC or CLI)99,118,132,133
2. Endovascular intervention versus surgical revascularization (1 RCT and 22 observational studies of 12,779 total patients with CLI and 2 RCTs and 10 observational studies of 565,168 total patients with either IC or CLI)38,39,99-131

### Detailed Synthesis

#### Effectiveness of Interventions

##### 1 Endovascular Intervention Versus Usual Care

In the CLI population, three observational studies compared endovascular intervention with usual care in patients (Table 22).99,118,133 These studies included a total of 562 patients. Of these studies, two were rated fair quality and one poor quality. Sample sizes for individual studies ranged from 70 to 304 patients. Study durations ranged from 12 to 18 months.

Table 22 Endovascular intervention versus usual care

Study Population | Type of Study N Analyzed^a^ Quality | Outcome Length of Followup | Results Reported by Authors
Patients with CLI
Lawall, 2009^133^ Patients with CLI | Observational N: 70 Poor | Mortality 18 mo Amputation 18 mo Hospital length of stay | Endovascular intervention: 25.5% Usual care: 26.7% Endovascular intervention: 14.5% Usual care: 26.7% Endovascular intervention: 20.9 ± 20.7 days Usual care: 24.4 ± 20.1 days
Varty, 1996^99^ Patients with CLI | Observational N: 188 Fair | Mortality 12 mo Limb salvage 12 mo Hospital length of stay, median | Endovascular intervention: 22% Usual care: 48% Endovascular intervention: 76% Usual care: not reported Endovascular intervention: 4.5 days Usual care: not reported
Faglia, 2012^118^ Patients with CLI | Observational N: 304 Fair | Mortality 18 mo Amputation 18 mo Hospital length of stay, mean | Endovascular intervention: 17.1% Usual care: 50% Endovascular intervention: 7.5% Usual care: 75% Endovascular intervention: 5.9 ± 3.5 days Usual care: 9.9 ± 2.9 days
Patients with IC or CLI
Kamiya, 2008^132^ Patients with IC or CLI | Observational N: 107 Fair | Mortality 30 mo Amputation 30 mo | Endovascular intervention: 5.5% Usual care: 5.8% Endovascular intervention: 5.5% Usual care: 3.8%

a Number of patients in the study arms of interest.

Abbreviation: mo=month/months

The mean age of study participants was 72 to 76 years of age. The proportion of female patients ranged from 30 to 43 percent. None of the studies reported the racial and ethnic demographics of the study participants.

All three studies were conducted in Europe. Funding source was reported as industry in one study,133 and no funding source was reported in the other two studies.

In the IC-CLI population, one observational study rated fair quality compared endovascular intervention with usual care (Table 22).132 This study included 107 patients with mean age of 71 years and 14 percent female patients. It did not report racial or ethnic demographics. This study was conducted in Japan with a government funding source.

###### Effect on All-Cause Mortality

All four observational studies reported the rate of survival/mortality during the course of followup. In the study by Lawall et al., mortality was slightly lower in the endovascular intervention group (25.5%) compared with usual care (26.7%) at 18 months of followup; however, in the study by Varty et al., mortality was much lower in the endovascular intervention group (22%) compared with usual care (48%) at 12 months of followup, and in the study by Faglia et al., mortality was also much lower in the endovascular group (17.1%) compared with the usual care group (50%) at 18 months of followup. There was no significant difference in the survival/mortality rates in the two comparison groups (5.5% in endovascular intervention and 5.8% in usual care) in Kamiya et al.132 at 30 months of followup.

###### Effect on Lower Extremity Amputation/Limb Salvage

All four observational studies also reported the rate of lower extremity amputation or limb salvage (the reverse of amputation) during the course of followup. In Lawall et al. and Faglia et al., the rate of amputation was lower in the endovascular intervention group (14.5% and 7.5% respectively) compared with usual care (26.7% and 75% respectively) at 18 months. In Varty et al., the limb salvage rate was 76 percent at 12 months, but the rate was not reported in the usual care group. In Kamiya et al.,132 there was no statistically significant difference in amputation rates between the endovascular intervention group (5.5%) compared with the usual care group (3.8%).

###### Effect on Amputation-Free Survival

Only Lawall et al.133 reported the rate of amputation-free survival at 18 months of followup, showing the endovascular intervention group at 60 percent compared with the usual care group at 46.7 percent.

###### Effect on Vessel Patency

None of the studies reported the outcome of vessel patency.

###### Effect on Hospital Length of Stay

The three observational studies in the CLI population reported the hospital length of stay during the index hospitalization. In Lawall et al., the hospital length of stay was lower in the endovascular intervention group (20.9 ± 20.7 days) compared with the usual care group (24.4 ± 20.1 days) at 18 months. In Faglia et al., the hospital length of stay was also lower in the endovascular group (5.9 ± 3.5 days) compared with the usual care group (9.9 ± 2.9 days). In Varty et al.99 the median hospital length of stay was 4.5 days at 12 months, but the duration was not reported in the usual care group.

##### 2 Endovascular Intervention Versus Surgical Revascularization

In the CLI population, 23 studies (1 RCT, 22 observational) compared endovascular with surgical revascularization. These studies included a total of 12,779 patients. Of these studies, the RCT134 was rated good quality, and of the observational studies, 1 was rated good quality, 11 fair quality, and 10 poor quality. Sample sizes for individual studies ranged from 73 to 4929 patients. Study durations ranged from 310 days to 84 months.

The mean age of study participants was 62 to 84 years of age. The proportion of female patients ranged from 1 to 57 percent. Only five studies (25%) reported the racial and ethnic demographics of the study participants.

Five studies (22%) were conducted within the United States or Canada, with the rest international. Funding source was reported in two studies (10%), with government agencies funding both of these studies.

In the IC-CLI population, 12 studies (2 RCTs, 10 observational) compared endovascular with surgical. These studies included a total of 565,168 patients. Of these studies, the 2 RCTs were rated fair quality, 4 of the 10 observational studies were rated fair quality and 6 were poor quality. Sample sizes for individual studies ranged from 44 to 563,143 patients. Study durations ranged from in hospital to 5 years.

The mean age of study participants was 62 to 70 years of age; median age was 66.5 years. The proportion of female patients ranged from 12 to 45 percent. Only one study reported the racial and ethnic demographics of the study participants.

Six studies (55%) were conducted within the United States or Canada, with the rest international. Funding source was reported in five studies (45%), with government, private foundation, nonprofit organization, grant and industry reported as the source of funding.

###### Effect on All-Cause Mortality

Twenty-four studies (18 in the CLI population and 6 in the IC-CLI population) reported the rate of survival/mortality during the course of followup (Table 23). Meta-analyses of the odds ratios were performed using Comprehensive Meta-Analysis Version 2.0 for short-term followup (≤6 months), intermediate-term followup (1 to 2 years), and long-term followup (≥3 years).

Table 23 Endovascular versus surgical revascularization: all-cause mortality

Study Population | Type of Study N Enrolled or Observed Quality | Outcome Length of Followup | Results Reported by Authors
Patients with CLI
Adam, 2005^39^ BASIL Study Patients with CLI | RCT N: 452 Good | Mortality 6 mo ≥3 yr | 6 mo Endovascular: 11.6% Surgical: 13.6% ≥3 yr Endovascular: 37.5% Surgery: 36%
Ah Chong, 2009^100^ Patients with CLI | Observational N: 464 Poor | Mortality In-hospital 1 yr 3 yr | In-hospital Endovascular: 3% Surgical: 8% 1yr Endovascular: 20% Surgical: 18% 3 yr Endovascular: 41% Surgical: 34%
Dorigo, 2009^101^ Patients with CLI | Observational N: 73 Fair | Mortality 1 yr | Endovascular: 11% Surgical: 37%
Dosluoglu 2012^119^ Patients with CLI | Observational N: 433 Fair | Mortality 1 yr 2 yr | 1 yr Endovascular: 28% Surgical: 27% 2 yr Endovascular: 40% Surgical: 34%
Faglia, 2012^118^ Patients with CLI | Observational N: 332 Fair | Mortality 30 days 18 mo | 30 days Endovascular: 0.7% Surgical: 0% 18 mo Endovascular: 17.1% Surgical: 28%
Hynes, 2004^102^ Patients with CLI | Observational N: 137 Fair | Mortality 30 days | [underlined: Femoropopliteal disease (N=102)] Endovascular: 0% Surgical: 4% [underlined: Aortoiliac disease (N=35)] Endovascular: 7% Surgical: 0%
Johnson, 1997^120^ Patients with CLI | Observational N: 150 Fair | Mortality 6 mo 1 yr | 6 mo Endovascular: 23% Surgical: 18% 1 yr Endovascular: 27% Surgical: 20%
Korhonen, 2011^105^ Patients with CLI | Observational N: 858 Good | Mortality 30 days 1 yr 3 yr | 30 days Endovascular: 5.1% Surgical: 2.4% 1 yr Endovascular: 24.3% Surgical: 17.8% 3 yr Endovascular: 41.1% Surgical: 35.0%
Kudo, 2006^106^ Patients with CLI | Observational N: 192 (237 limbs) Poor | Mortality 5 yr | Endovascular: 52% Surgical: 54%
Laurila, 2000^107^ Patients with CLI | Observational N; 124 (124 limbs) Poor | Mortality 30 days 20 mo | 30 days Endovascular: 0% Surgical: 5% 20 mo Endovascular: 20% Surgical: 35%
Loor, 2009^108^ Patients with CLI | Observational N: 92 Fair | Mortality 1 yr | Endovascular: 13% Surgical: 24%
Soderstrom, 2010^110^ Patients with CLI | Observational N: 1023 Fair | Mortality 30 days 1 yr 5 yr | 30 days Endovascular: 3.5% Surgical: 5.8% 1 yr Endovascular: 26.7% Surgical: 24.2% 5 yr Endovascular: 52.5% Surgical: 56.7
Sultan, 2009^109^ Patients with CLI | Observational N: 309 Fair | Mortality Perioperative 5 yr | Perioperative Endovascular: 1.6% Surgical: 3.4% 5 yr Endovascular: 78.6% Surgical: 80.1%
Taylor, 2006^111^ Patients with CLI | Observational N: 841 Poor | Mortality 5 yr | Endovascular: 40.4% Surgical: 41.9%
Varela, 2011^114^ Patients with CLI | Observational N: 88 (91 limbs) Fair | Mortality 2 yr | Endovascular: 19% Surgical: 21%
Varty, 1996^99^ Patients with CLI | Observational N: 188 Fair | Mortality In-hospital 1 yr | In-hospital Endovascular: 3.7% Surgical: 4% 1yr Endovascular: 22% Surgical: 9%
Wolfle, 2000^116^ Patients with CLI | Observational N: 209 Poor | Mortality 30 days 84 mo | 30 days Endovascular: 5.9% Surgical: 2.3% 84 mo Endovascular: 37% Surgical: 51%
Zdanowski, 1998^117^ Patients with CLI | Observational N: 4929 Poor | Mortality 30 days 1 yr | 30 days Endovascular: 5.0% Surgical: 5.4% 1yr Endovascular: 22.9% Surgical: 22.9%
Patients with IC or CLI
Dosluoglu, 2010^38^ Patients with IC or CLI | Observational IC: 38% in endovascular arm, 25% in surgical and hybrid arms CLI: 62% in endovascular arm, 75% in surgical and hybrid arms N: 654 Poor | Mortality 30 days | Endovascular: 1.1% Surgical: 3.1%
Janne d'Othee, 2008^122^ Patients with IC or CLI | Observational IC: 97 patients CLI: Not reported N: 97 Fair | Mortality 30 days 1 yr | 30 days Endovascular: 0% Surgical: 0% 1 yr Endovascular: 9.4% Surgical: 15.2%
Kashyap, 2008^131^ Patients with IC or CLI | Observational IC: 54% in endovascular arm, 51% in surgical arm CLI: 46% in endovascular arm, 49% in surgical arm N: 169 Fair | Mortality 30 days | Endovascular: 4.8% Surgical: 8.1%
Lepantalo, 2009^123^ Patients with IC or CLI | RCT IC: 87% in endovascular arm, 90% in surgical arm CLI: 13% in endovascular arm, 10% in surgical arm N: 44 Fair | Mortality 30 days 18 mo | 30 days Endovascular: 0% Surgical: 0% 18 mo Endovascular: 4.3% Surgical: 9.5%
McQuade, 2009^124^ Patients with IC or CLI | RCT IC: 82% in endovascular arm, 62% in surgical arm CLI: 18% in endovascular arm, 38% in surgical arm N: 86 Fair | Mortality 18 mo 2 yr 4 yr | 18 mo Endovascular: 8.0% Surgical: 8.0% 2 yr Endovascular: 15.4% Surgical: 12.5% 4 yr Endovascular: 28.1% Surgical: 30.8%
Rossi, 1998^125^ Patients with IC or CLI | Observational IC: 24% in endovascular arm, 0% in surgical arm CLI: 76% in endovascular arm, 100% in surgical arm N: 48 Poor | Mortality 1 yr | Endovascular: 27.0% Surgical: 45.5%

Abbreviations: CLI=critical limb ischemia; IC=intermittent claudication; mo=month/months; N=number

###### Mortality Less Than or Equal to 6 Months After Enrollment

Figure 22 shows the forest plot for the mortality meta-analysis at the ≤6-month time point. One RCT (good quality, CLI population) and 13 observational studies (1 good quality, 6 fair, and 4 poor in the CLI population and 1 fair and 1 poor in the IC-CLI population) reporting the rate of survival/mortality less than or equal to 6 months after enrollment. One RCT123 and one observational study122 reported no deaths in either group at 30 days and therefore were not included in the analysis.

Figure 22 Forest plot for meta-analysis of mortality at ≤6 mo in the CLI and IC-CLI populations

Abbreviations: CI=confidence interval; CLI=critical limb ischemia; IC=intermittent claudication; Obs=observational; RCT=randomized controlled trial.

This figure shows the forest plot for the mortality meta-analysis at the ≤6 month time point. The result was a summary estimated odds ratio for the eleven CLI observational studies (CLI-Obs) of 0.85 (95% CI, 0.57 to 1.27, p=0.43); for the one CLI RCT study (CLI-RCT), the summary estimated odds ratio was 0.51 (CI, 0.20 to 1.35, p=0.18); and for the two IC-CLI observational studies (IC-CLI-Obs), the summary estimated odds ratio was 0.45 (CI, 0.18 to 1.09, p=0.08).

Summary estimates for the CLI observational studies (CLI-Obs) were OR 0.85 (95% CI, 0.57 to 1.27, p=0.43); for the CLI RCT study (CLI-RCT), OR 0.51 (CI, 0.20 to 1.35, p=0.18); and for the IC-CLI observational studies (IC-CLI-Obs), OR 0.45 (CI, 0.18 to 1.09, p=0.08). The forest plot shows the comparisons between the summary estimates by study design and population; all estimates favored endovascular intervention although did not reach statistical significance, but this was seen more in the IC-CLI observational studies and the CLI RCT. The overall SOE was rated low for all study populations and study designs, due to the large number of poor- and fair-quality observational studies, with only one good RCT, the inconsistency of the CLI-Obs studies, and imprecision of these findings.

###### Mortality at 1 to 2 Years After Enrollment

Figure 23 shows the forest plot for the mortality meta-analysis at the 1- to 2-year time point. Two RCTs (both fair quality in the IC-CLI population) and 14 observational studies (1 good quality, 8 fair, and 3 poor in the CLI population and 1 fair and 1 poor in the IC-CLI population) reporting the rate of survival/mortality at 1 to 2 years after enrollment.

Figure 23 Forest plot for meta-analysis of mortality at 1-2 yr in the CLI and IC-CLI populations

Abbreviations: CI=confidence interval; CLI=critical limb ischemia; IC=intermittent claudication; Obs=observational; RCT=randomized controlled trial.

This figure shows the forest plot for the mortality meta-analysis at the 1 to 2 year time point. The results was a summary estimated odds ratio for the twelve CLI observational studies (CLI-Obs) of 1.01 (95% CI, 0.80 to 1.28, p=0.91); for the two IC-CLI observation studies (IC-CLI-Obs), the summary estimated odds ratio was 0.51 (CI, 0.20 to 1.31, p=0.16); and for the two IC-CLI RCT studies (IC-CLI-RCT), the summary estimated odds ratio was 0.81 (CI, 0.23 to 2.82, p=0.74).

The summary estimates for the CLI observational studies (CLI-Obs) were OR 1.01 (95% CI, 0.80 to 1.28, p=0.91); for the IC-CLI observational studies (IC-CLI-Obs), OR 0.51 (CI, 0.20 to 1.31, p=0.16); and for the IC-CLI RCT studies (IC-CLI-RCT), OR 0.81 (CI, 0.23 to 2.82, p=0.74). The forest plot shows the comparisons between the summary estimates by study design and population. The summary estimate for IC-CLI observational studies favors endovascular intervention although it did not reach statistical significance. The summary estimates of the 10 CLI observational studies and the 2 IC-CLI RCTs also failed to show a significant difference between the two procedures at 1 to 2 years. The overall SOE was rated low on the basis of two RCTs and 12 observational studies, with inconsistent results of a direct outcome and a wide confidence interval.

###### Mortality at 3 or More Years After Enrollment

Figure 24 shows the forest plot for the mortality meta-analysis at the 3+ year time point. Two RCTs (one good-quality study in the CLI population and one fair-quality study in the IC-CLI population) and seven observational studies (one good quality, three fair, and three poor in the CLI population) reported the rate of survival/mortality at 3+ years after enrollment.

Figure 24 Forest plot for meta-analysis of mortality at ≥3 yr in CLI and IC-CLI populations

Abbreviations: CI=confidence interval; CLI=critical limb ischemia; IC=intermittent claudication; Obs=observational; RCT=randomized controlled trial.

This figure shows the forest plot for the mortality meta-analysis at the 3+ year time point. The result was a summary estimated odds ratio for the seven CLI observational studies (CLI-Obs) of 1.05 (95% CI, 0.54 to 2.06, p=0.88); for the one CLI RCT study (CLI-RCT), the summary estimated odds ratio was 1.07 (CI, 0.73 to 1.56, p=0.74); and for the one IC-CLI RCT study (IC-CLI-RCT), the summary estimated odds ratio was 0.88 (CI, 0.28 to 2.73, p=0.82).

The summary estimates for the CLI observational studies (CLI-Obs) were OR 1.05 (95% CI, 0.54 to 2.06, p=0.88); for the CLI RCT (CLI-RCT), OR 1.07 (CI, 0.73 to 1.56, p=0.74); and for the IC-CLI RCT studies (IC-CLI-RCT), OR 0.88 (CI, 0.28 to 2.73, p=0.82); all demonstrating no difference between treatments. The overall SOE was rated low for the CLI population on the basis of inconsistent results of a direct outcome and a wide confidence interval. The results from the IC-CLI population are inconclusive and therefore the SOE was rated insufficient.

###### Effect on Nonfatal MI

Only the BASIL study39 reported the in-hospital rate of nonfatal MI of 3 percent in the endovascular intervention group compared with 8 percent in the surgical group.

###### Effect on Lower Extremity Amputation

Twenty-one studies (17 in the CLI population and 4 in the IC-CLI population) reported the rate of lower extremity amputation during the course of followup (Table 24). Meta-analyses of the odds ratios were performed using Comprehensive Meta-Analysis Version 2.0 for intermediate-term followup (1 year) and long-term followup (2 to 3 years and 5 or more years).

Table 24 Endovascular versus surgical revascularization: lower extremity amputation

Study Population | Type of Study N Analyzed^a^ Quality | Outcome Length of Followup | Results Reported by Authors
Patients with CLI
Adam, 2005^39^ BASIL Study Patients with CLI | RCT N: 452 Good | Amputation 6 mo 1 yr 3 yr | 6 mo Endovascular: 4.5% Surgical: 2.6% 1 yr Endovascular: 14.7% Surgical: 12.3% 3 yr Endovascular: 19.2% Surgical: 18.9%
Ah Chong, 2009^100^ Patients with CLI | Observational N: 464 Poor | Limb salvage 1 yr 3 yr 5 yr | 1 yr Endovascular: 93% Surgical: 82% 3 yr Endovascular: 89% Surgical: 78% 5 yr Endovascular: 77% Surgical: 76%
Dorigo, 2009^101^ Patients with CLI | Observational N: 73 Fair | Limb salvage 1 yr | Endovascular: 96.8% Surgical: 88.2%
Dosluoglu 2012^119^ Patients with CLI | Observational N: 433 Fair | Limb salvage 5 yr | Endovascular: 78% Surgical: 78%
Faglia, 2012^118^ Patients with CLI | Observational N: 332 Fair | Major amputation 30 days 18 mo | 30 days Endovascular: 2.7% Surgical: 7.5% 18 mo Endovascular: 7.5% Surgical: 20%
Hynes, 2004^102^ Patients with CLI | Observational N: 137 Fair | Limb salvage 1 yr | [underlined: Femoropopliteal disease (N=102)] Endovascular: 97% Surgical: 82% [underlined: Aortoiliac disease (N=35)] Endovascular: 100% Surgical:86%
Korhonen, 2011^105^ Patients with CLI | Observational N: 858 Good | Limb salvage 1 yr 3 yr 5 yr | 1 yr Endovascular: 87% Surgical: 95% 3 yr Endovascular: 77.0% Surgical: 79.3% 5 yr Endovascular: 75.3% Surgical: 76.0%
Kudo, 2006^106^ Patients with CLI | Observational N: 192 (237 limbs) Poor | Limb salvage 5 yr | Endovascular: 91% Surgical: 77%
Loor, 2009^108^ Patients with CLI | Observational N: 92 Fair | Limb salvage 1 yr | Endovascular: 87% Surgical: 69%
Soderstrom, 2010^110^ Patients with CLI | Observational N: 1023 Fair | Limb salvage 1 yr 3 yr 5 yr | 1 yr Endovascular: 85.5% Surgical: 82.2% 3 yr Endovascular: 77.0% Surgical: 79.3% 5 yr Endovascular: 75.3% Surgical: 76.0%
Sultan, 2009^109^ Patients with CLI | Observational N: 309 Fair | Major amputation 5 yr | Endovascular: 27.1% Surgical: 28.8%
Taylor, 2005^112^ | Observational N: 122 Fair | Limb salvage 2-3 yr | Endovascular: 74.3% Surgical: 82.5%
Taylor, 2006^111^ Patients with CLI | Observational N: 841 Poor | Limb Salvage 1 yr | Endovascular: 76.5% Surgical: 82.4%
Varela, 2011^114^ Patients with CLI | Observational N: 88 (91 limbs) Fair | Limb salvage 2 yr | Endovascular: 83% Surgical: 72%
Varty, 1996^99^ Patients with CLI | Observational N: 188 Fair | Limb salvage 1 yr | 1 yr Endovascular: 76% Surgical: 76%
Venermo, 2011^115^ Patients with CLI | Observational N: 597 Poor | Limb salvage 1 yr | Endovascular: 88.3% Surgical: 84.9%
Wolfle, 2000^116^ Patients with CLI | Observational N: 209 Poor | Limb salvage 1 yr 6 yr | 1 yr Endovascular: 82% Surgical: 80% 6 yr Endovascular: 63% Surgical: 69%
Patients with IC or CLI
Dosluoglu, 2010^38^ Patients with IC or CLI | Observational IC: 38% in endovascular arm, 25% in surgical and hybrid arms CLI: 62% in endovascular arm, 75% in surgical and hybrid arms N: 654 Poor | Amputation 30 days Limb salvage 1 yr 3 yr | 30 days Endovascular: 2.1% Surgical: 1.8% 1 yr Endovascular: 86% Surgical: 80% 3 yr Endovascular: 80% Surgical: 74%
Kashyap, 2008^131^ Patients with IC or CLI | Observational IC: 54% in endovascular arm, 51% in surgical arm CLI: 46% in endovascular arm, 49% in surgical arm N: 169 Fair | Amputation 1 yr 2 yr 3 yr | 1 yr Endovascular: 2% Surgical: 2% 2 yr Endovascular: 2% Surgical: 2% 3yr Endovascular: 2% Surgical: 2%
Lepantalo, 2009^123^ Patients with IC or CLI | RCT IC: 87% in endovascular arm, 90% in surgical arm CLI: 13% in endovascular arm, 10% in surgical arm N: 44 Fair | Amputation 18 mo | Endovascular: 0% Surgical: 4.8%
McQuade, 2009^124^ Patients with IC or CLI | RCT IC: 82% in endovascular arm, 62% in surgical arm CLI: 18% in endovascular arm, 38% in surgical arm N: 86 Fair | Amputation 18 mo 2 yr 4 yr | 18 mo Endovascular: 3.1% Surgical: 13.5% 2 yr Endovascular: 2.6% Surgical: 12.5% 4 yr Endovascular: 3.1% Surgical: 23.1%

a Number of patients in the study arms of interest.

Abbreviations: CLI=critical limb ischemia; IC=intermittent claudication; mo=month/months; yr=year/years.

###### Amputation at Less Than 2 Years After Enrollment

Figure 25 shows the forest plot for the amputation meta-analysis at the less than 2 year time point. Three RCTs (one good quality in the CLI population and two fair quality in the IC-CLI population) and 13 observational studies (1 good quality, 6 fair, and 3 poor in the CLI population and 1 fair and 1 poor in the IC-CLI population) reported the rate of amputation at less than 2 years after enrollment.

Figure 25 Forest plot for meta-analysis of amputation at less than 2 years in the CLI and IC-CLI populations

Abbreviations: CI=confidence interval; CLI=critical limb ischemia; IC=intermittent claudication; Obs=observational; RCT=randomized controlled trial.

This figure shows the forest plot for the amputation meta-analysis at the <2 year time point. The result was a summary estimated odds ratio for the eleven CLI observational studies (CLI-Obs) of 0.73 (95% CI, 0.48 to 1.09, p=0.12); for the one CLI RCT study (CLI-RCT), the summary estimated odds ratio was 1.23 (CI, 0.72 to 2.11, p=0.46); for the two IC-CLI observational studies (IC-CLI-Obs), the summary estimated odds ratio was 1.11 (CI, 0.40 to 3.05, p=0.84); and for the two IC-CLI RCT studies (IC-CLI-RCT), the summary estimated odds ratio was 0.22 (CI, 0.05 to 1.07, p=0.06).

The summary estimates did not demonstrate a difference for the CLI observational studies (CLI-Obs) OR 0.73 (95% CI, 0.48 to 1.09, p=0.12); for the CLI RCT study (CLI-RCT), OR 1.23 (CI, 0.72 to 2.11, p=0.46); or for the IC-CLI observational studies (IC-CLI-Obs), OR 1.11 (CI, 0.40 to 3.05, p=0.84). The IC-CLI RCT studies (IC-CLI-RCT) showed a trend toward a benefit of endovascular intervention but did not reach statistical significance, OR 0.22 (CI, 0.05 to 1.07, p=0.06). The forest plot shows the comparisons between the summary estimates by study design and population. There was heterogeneity within and between populations and between study designs. The observational studies are influenced by selection bias. The differences in the RCT population results are due to the PAD severity, such that the IC-CLI RCTs favor endovascular intervention (although with confidence intervals crossing 1), and the CLI RCT does not demonstrate a difference. The overall SOE was rated low for the CLI population on the basis of inconsistent results of a direct outcome and a wide confidence interval. The results from the IC-CLI population are inconclusive and therefore the SOE was rated insufficient.

###### Amputation at 2 to 3 Years After Enrollment

Figure 26 shows the forest plot for the amputation meta-analysis at the 2- to 3-year time point. Two RCTs (one good quality in the CLI population and one fair quality in the IC-CLI population) and five observational studies (one good quality, two fair, and one poor in the CLI population and one fair in the IC-CLI population) reported the rate of amputation at 2 to 3 years after enrollment.

Figure 26 Forest plot for meta-analysis of amputation at 2 to 3 years in the CLI and IC-CLI populations

Abbreviations: CI=confidence interval; CLI=critical limb ischemia; IC=intermittent claudication; Obs=observational; RCT=randomized controlled trial.

This figure shows the forest plot for the amputation meta-analysis at the 2 to 3 year time point. The result was a summary estimated odds ratio for the four CLI observational studies (CLI-Obs) of 1.08 (95% CI, 0.62 to 1.89, p=0.78); for the one CLI RCT study (CLI-RCT), the summary estimated odds ratio was 1.02 (CI, 0.64 to 1.63, p=0.94); for the one IC-CLI observation study (Obs-IC-CLI), the summary estimated odds ratio was 1.00 (CI, 0.18 to 5.54, p=1.00); and for the one IC-CLI RCT study (IC-CLI-Obs), the summary estimated odds ratio was 0.18 (CI, 0.03 to 1.29, p=0.09).

The summary estimates for the CLI observational studies (CLI-Obs) were OR 1.08 (95% CI, 0.62 to 1.89, p=0.78); for the CLI RCT study (CLI-RCT), OR 1.02 (CI, 0.64 to 1.63, p=0.94); and for the IC-CLI observational studies (IC-CLI-Obs), OR 1.00 (CI, 0.18 to 5.54, p=1.00); all demonstrating no difference between treatments. For the IC-CLI RCT study (IC-CLI-RCT), a trend toward a benefit of endovascular interventions was seen, OR 0.18 (CI, 0.03 to 1.29, p=0.09) but it did not reach statistical significance. The forest plot shows the comparisons between the summary estimates by study design and population. Given the small number of events and total study populations in the IC-CLI observational and RCT studies, the differences in the summary estimate are likely to change with the addition of studies. The overall SOE was rated low for the CLI population. The results from the IC-CLI population are inconclusive and therefore the SOE was rated insufficient.

###### Amputation at 5 Years After Enrollment

Figure 27 shows the forest plot for this meta-analysis in the CLI population. Seven observational studies (one good quality, three fair, and three poor) reporting the rate of lower extremity amputation after 5 years found that the odds ratio for endovascular intervention was 1.06 (95% CI, 0.70 to 1.59, p=0.79) showing no statistically significant difference in revascularization strategies in the long term. There was evidence of extreme heterogeneity, with a Q-value of 24.69 for 5 degrees of freedom, p<0.001. The cause of heterogeneity is not readily apparent since all are single-center studies comparing angioplasty with surgical bypass. In some studies, concomitant therapy with clopidogrel, aspirin, and/or LMWH was described. The overall SOE was rated low on the basis of only observational studies with inconsistent results of a direct outcome and a wide confidence interval.

Figure 27 Forest plot for meta-analysis of amputation after 5 years in the CLI population

Abbreviations: CI=confidence interval; CLI=critical limb ischemia; IC=intermittent claudication; Obs=observational; RCT=randomized controlled trial.

This figure shows the forest plot for the amputation meta-analysis at the >5 year time point for the CLI population. The result was a summary estimated odds ratio for the seven observational studies of 1.06 (95% CI, 0.70 to 1.59, p=0.79) showing no statistically significant difference in revascularization strategies in the long term.

There were no studies of the IC-CLI population with longer than 5 years of followup. The overall SOE of the amputation outcome was rated insufficient for the mixed PAD population at 5 or more years.

###### Effect on Amputation-Free Survival

Seven studies in the CLI population reported the rate of amputation-free survival (time to death or major amputation during followup) (Table 25). From the studies of IC-CLI population, only two reported amputation-free survival. Both studies were observational; one was a report from an administrative dataset,126 and one was a study that reported data from a subgroup of hemodialysis-dependent patients.121 Therefore, these studies were not included in the meta-analysis. The Zdanowski study was not included in the meta-analysis since it was the only study with a 30-day followup.117 Meta-analyses of the odds ratios were performed using Comprehensive Meta-Analysis Version 2.0 for intermediate-term followup (1 year) and long-term followup (2 to 3 years and 5 or more years).

Table 25 Endovascular versus surgical revascularization: amputation-free survival

Study Population | Type of Study N Analyzed^a^ Quality | Outcome Length of Followup | Results Reported by Authors
Patients with CLI
Adam, 2005^39^ BASIL Study Patients with CLI | RCT N: 452 Good | Amputation-free survival 1 yr 3 yr | 1 yr Endovascular: 68% Surgical: 71% 3 yr Endovascular: 57% Surgical: 52%
Dosluoglu 2012^119^ Patients with CLI | Observational N: 433 Fair | Amputation-free survival 5 yr | Endovascular: 30% Surgical: 39%
Korhonen, 2011^105^ Patients with CLI | Observational N: 858 Good | Amputation-free survival 1 yr 2 yr 3 yr 5 yr | 1 yr Endovascular: 70.0% Surgical:79.9% 2 yr Endovascular: 60.2% Surgical: 72.6% 3 yr Endovascular: 52.1% Surgical: 61.0% 5 yr Endovascular: 42.0% Surgical: 53.7%
Soderstrom, 2010^110^ Patients with CLI | Observational N: 1023 Fair | Amputation-free survival 1 yr 3 yr 5 yr | 1 yr Endovascular: 64.6% Surgical: 65.9% 3 yr Endovascular: 43.6% Surgical: 49.1% 5 yr Endovascular: 37.7% Surgical: 37.3%
Sultan, 2009^109^ Patients with CLI | Observational N: 309 Fair | Amputation-free survival 5 yr | Endovascular: 72.9% Surgical: 71.2%
Varela, 2011^114^ Patients with CLI | Observational N: 88 (91 limbs) Fair | Amputation-free survival 2 yr | Endovascular: 73% Surgical: 66%
Zdanowski, 1998^117^ Patients with CLI | Observational N: 4929 Poor | Amputation-free survival 30 days | Endovascular: 90% Surgical: 89.8%

a Number of patients in the study arms of interest.

Abbreviations: CLI=critical limb ischemia; IC=intermittent claudication; mo=month/months; RCT=randomized controlled trial; yr=year/years.

###### Amputation-Free Survival at 1 Year After Enrollment

Figure 28 shows the forest plot for this meta-analysis of two observational studies (1 good, 1 fair) and one RCT (good quality) reporting the rate of amputation-free survival. The observational studies found a summary odds ratio for endovascular versus surgical revascularization of 0.76 (95% CI, 0.48 to 1.21, p=0.24) favoring endovascular treatment at 1 year, which was not statistically significant. The odds ratio for the RCT39 was 0.87 (CI, 0.58 to 1.30, p=0.49) and is consistent with the findings from the two observational studies. There was no evidence of heterogeneity, with a Q-value of 3.26 for 2 degrees of freedom, p=0.20. The summary estimate is provided in the figure because of the similar patient population and consistency of findings. The overall SOE was rated low.

Figure 28 Forest plot for meta-analysis of amputation-free survival at 1 year in the CLI population

Abbreviations: CI=confidence interval; CLI=critical limb ischemia; Obs=observational; RCT=randomized controlled trial.

This figure shows the forest plot for the amputation-free survival meta-analysis at the 1 year time point for the CLI population. The result was a summary estimated odds ratio for the two CLI observational studies (CLI-Obs) of 0.76 (95% CI, 0.48 to 1.21, p=0.24) favoring endovascular treatment at 1 year, which was not statistically significant. For the one CLI RCT study (CLI-RCT), the summary estimated odds ratio was 0.87 (CI, 0.58 to 1.30, p=0.49) showing findings consistent with the two observational studies. The overall summary estimated odds ratio was 0.82 (CI, 0.61 to 1.11, p=0.20).

###### Amputation-Free Survival at 2 to 3 Years After Enrollment

Figure 29 shows the forest plot for this meta-analysis of one good-quality RCT and three observational studies (one good, two fair) reporting the rate of amputation-free survival at 2 to 3 years. The summary estimate for the observational studies (CLI-Obs) was OR 0.76 (95% CI, 0.53 to 1.09, p=0.13). The odds ratio for the RCT was 1.22 (CI, 0.84 to 1.77, p=0.29).

Figure 29 Forest plot for meta-analysis of amputation-free survival at 2 to 3 years in the CLI population

Abbreviations: CI=confidence interval; CLI=critical limb ischemia; Obs=observational; RCT=randomized controlled trial.

This figure shows the forest plot for the amputation-free survival meta-analysis at the 2 to 3 year time point for the CLI population. The result was a summary estimated odds ratio for the three CLI observational studies (CLI-Obs) of 0.76 (95% CI, 0.53 to 1.09, p=0.13) showing no difference between revascularization strategies at 2 to 3 years. For the one CLI RCT study (CLI-RCT), the summary estimated odds ratio was 1.22 (CI, 0.84 to 1.77, p=0.29) favoring surgical revascularization.

There was evidence of heterogeneity, with both the Adam (RCT)39 and Varela114 studies favoring surgical revascularization. In the Varela study, the event rate was based on the number of affected limbs while the other analyses were at the patient level. The Adam study is an older RCT; therefore the advances in endovascular technique may affect the summary estimate. The overall SOE was rated low on the basis of one good-quality RCT and three observational studies with inconsistent results of a direct outcome and a wide confidence interval.

###### Amputation-Free Survival 5 Years After Enrollment

Figure 30 shows the forest plot for this meta-analysis. Four observational studies (one good quality, three fair) reporting the rate of amputation-free survival found that the odds ratio for endovascular versus surgical revascularization was 0.89 (95% CI, 0.59 to 1.34, p=0.58), showing no statistically significant difference in revascularization strategies in the long term. There was evidence of heterogeneity, with a Q-value of 12.80 for 3 degrees of freedom, p=0.005. Differences in selection bias, study location, and use of antiplatelet therapy may explain the differences among the Korhonen study,105 the Dosluoglu study,119 and the other studies. The overall SOE was rated low on the basis of only observational studies with inconsistent results of a direct outcome and a wide confidence interval.

Figure 30 Forest plot for meta-analysis of amputation-free survival after 5 years in the CLI population

Abbreviations: CI=confidence interval; CLI=critical limb ischemia; Obs=observational; RCT=randomized controlled trial.

This figure shows the forest plot for the amputation-free survival meta-analysis at the >5 year time point for the CLI population. The result was a summary estimated odds ratio for the four observational studies of 0.89 (95% CI, 0.59 to 1.34, p=0.58) showing no statistically significant difference in revascularization strategies in the long term.

###### Effect on Wound Healing

One study in the CLI population (fair quality)114 reported the incidence of wound healing during the study followup. The percentage of patients with wound healing and the mean time to wound healing were both improved with surgical revascularization when compared with endovascular revascularization. Due to a single study reporting this outcome, the SOE was rated insufficient.

###### Effect on Vessel Patency

Fourteen studies reported the rate of vessel patency during the course of followup (Table 26). Nine studies in the CLI population and five studies in the IC-CLI population reported the rate of primary patency (following initial intervention), and eight studies in the CLI population and two studies in the IC-CLI population reported the rate of secondary patency (following screening and repeat intervention, often referred to as assisted patency). Meta-analyses of the odds ratios were performed using Comprehensive Meta-Analysis Version 2.0 for intermediate-term followup (1 year) and long-term followup (2 to 3 years).

Table 26 Endovascular versus surgical revascularization: vessel patency

Study Population | Type of Study N Analyzed^a^ Quality | Outcome Length of Followup | Results Reported by Authors
Patients with CLI
Ah Chong, 2009^100^ Patients with CLI | Observational N: 464 Poor | Primary patency 1 yr 3 yr | Primary patency 1 yr Endovascular: 48% Surgical: 65% 3 yr Endovascular: 27% Surgical: 65%
Ah Chong, 2009^100^ Patients with CLI | Observational N: 464 Poor | Secondary patency 1 yr 3 yr | Secondary patency 1 yr Endovascular: 61% Surgical: 74% 3 yr Endovascular: 31% Surgical: 58%
Dorigo, 2009^101^ Patients with CLI | Observational N: 73 Fair | Primary patency 1 yr Secondary patency 1 yr | Endovascular: 58.9% Surgical: 67.9% Endovascular: 67.9% Surgical: 81.9%
Dosluoglu 2012^119^ Patients with CLI | Observational N: 433 Fair | Primary patency 5 yr Secondary patency 5 yr | Endovascular: 50% Surgical: 48% Endovascular: 73% Surgical: 64%
Hynes, 2004^102^ Patients with CLI | Observational N: 137 Fair | Primary patency 2 yr | [underlined: Femoropopliteal disease (N=102)] Endovascular: 84% Surgical: 68% [underlined: Aortoiliac disease (N=35)] Endovascular: 93% Surgical:81%
Hynes, 2004^102^ Patients with CLI | Observational N: 137 Fair | Secondary patency 2 yr | [underlined: Femoropopliteal disease (N=102)] Endovascular: 98% Surgical: 100% [underlined: Aortoiliac disease (N=35)] Endovascular: 100% Surgical: 95%
Jerabek, 2003^103^ Patients with CLI | Observational N: 131 Poor | Primary patency 18 mo | Endovascular: 83.3% Surgical: 87.4%
Kudo, 2006^106^ Patients with CLI | Observational N: 192 (237 limbs) Poor | Primary patency 5 yr Secondary patency 5 yr | Endovascular: 44% Surgical: 28% Endovascular: 88% Surgical: 57%
Loor, 2009^108^ Patients with CLI | Observational N: 92 Fair | Primary patency 1 yr Secondary patency 1 yr | Endovascular: 63% Surgical: 64% Endovascular: 76% Surgical: 75%
Taylor, 2005^112^ Patients with CLI | Observational N: 122 Fair | Primary patency 1 yr 2 yr 3 yr | Primary patency 1 yr Endovascular: 62.0% Surgical: 67.7% 2 yr Endovascular: 55.3% Surgical: 63.3% 3 yr Endovascular: 48.4% Surgical: 60.5%
Taylor, 2005^112^ Patients with CLI | Observational N: 122 Fair | Secondary patency 1 yr 2 yr 3 yr | Secondary patency 1 yr Endovascular: 74.1% Surgical: 87.4% 2 yr Endovascular: 70.7% Surgical: 80.1% 3 yr Endovascular: 63.7% Surgical: 80.1%
Varela, 2011^114^ Patients with CLI | Observational N: 88 (91 limbs) Fair | Primary patency 2 yr Secondary patency 2 yr | Endovascular: 76% Surgical: 72% Endovascular: 82% Surgical: 82%
Patients with IC or CLI
Janne d'Othee, 2008^122^ Patients with IC or CLI | Observational IC: 97 patients CLI: Not reported N: 97 Fair | Primary patency Secondary patency 30 days 1 yr | Primary patency 30 day Endovascular: 98% Surgical: 100% 1 yr Endovascular: 94% Surgical: 95% Secondary patency 30 day Endovascular: 100% Surgical: 100%
Kashyap, 2008^131^ Patients with IC or CLI | Observational IC: 54% in endovascular arm, 51% in surgical arm CLI: 46% in endovascular arm, 49% in surgical arm N: 169 Fair | Primary patency 1 yr 2 yr 3 yr | 1 yr Endovascular: 90% Surgical: 93% 2 yr Endovascular: 92% Surgical: 93% 3 yr Endovascular: 74% Surgical: 93%
Lepantalo, 2009^123^ Patients with IC or CLI | RCT IC: 87% in endovascular arm, 90% in surgical arm CLI: 13% in endovascular arm, 10% in surgical arm N: 44 Fair | Primary patency 1 yr | Primary patency Endovascular: 46% Surgical: 84% Secondary patency Endovascular: 63% Surgical: 100%
McQuade, 2009^124^ Patients with IC or CLI | RCT IC: 82% in endovascular arm, 62% in surgical arm CLI: 18% in endovascular arm, 38% in surgical arm N: 86 Fair | Primary patency 1 yr 2 yr 3 yr 4 yr | 1 yr Endovascular: 72% Surgical: 76% 2 yr Endovascular: 63% Surgical: 63% 3 yr Endovascular: 63% Surgical: 63% 4 yr Endovascular: 59% Surgical: 58%
Timaran, 2003^129^ Patients with IC or CLI | Observational IC: 59% of total population CLI: 41% of total population N: 62 patients (68 procedures) Poor | Primary patency 1 yr 3 yr | 1 yr Endovascular: 85% Surgical: 89% 3 yr Endovascular: 72% Surgical: 86%

a Number of patients in the study arms of interest.

Abbreviations: CLI=critical limb ischemia; IC=intermittent claudication; mo=month/months; yr=year/years.

###### Primary Patency at 1 Year After Enrollment

Figure 31 shows the forest plot for the primary patency meta-analysis at the 1-year time point. Two RCTs (both fair quality in the IC-CLI population) and eight observational studies (three fair and two poor in the CLI population and three fair in the IC-CLI population) reported the rate of primary patency at 1 year after enrollment.

Figure 31 Forest plot for meta-analysis of primary patency at 1 year in the CLI and IC-CLI populations

Abbreviations: CI=confidence interval; CLI=critical limb ischemia; IC=intermittent claudication; Obs=observational; RCT=randomized controlled trial.

This figure shows the forest plot for the primary patency meta-analysis at the 1 year time point. The result was a summary estimated odds ratio for the five CLI observational studies (CLI-Obs) of 0.63 (95% CI, 0.46 to 0.86, p=0.00); for the three IC-CLI observational studies (IC-CLI-Obs), the summary estimated odds ratio was 0.71 (CI, 0.40 to 1.28, p=0.26); and for the two IC-CLI RCT studies (IC-CLI-RCT), the summary estimated odds ratio was 0.40 (CI, 0.08 to 1.93, p=0.26).

The summary estimates for the CLI observational studies (CLI-Obs) were OR 0.63 (95% CI, 0.46 to 0.86, p=0.00); for the IC-CLI observational studies (IC-CLI-Obs), OR 0.71 (CI, 0.40 to 1.28, p=0.26); and for the IC-CLI RCT studies (IC-CLI-RCT), OR 0.40 (CI, 0.08 to 1.93, p=0.26). The forest plot shows the comparisons between the summary estimates by study design and population. The CLI observational studies (three fair quality and two poor) are consistent, direct, and precise (moderate SOE). The overall SOE was rated low for the IC-CLI observational studies and RCTs due to the inconsistency and imprecision.

###### Primary Patency at 2 to 3 Years After Enrollment

Figure 32 shows the forest plot for the primary patency meta-analysis at the 2- to 3-year time point. One RCT (fair quality in the IC-CLI population) and six observational studies (three fair and one poor in the CLI population and two fair in the IC-CLI population) reporting the rate of primary patency at 2-3 years after enrollment.

Figure 32 Forest plot for meta-analysis of primary patency at 2 to 3 years in the CLI and IC-CLI populations

Abbreviations: CI=confidence interval; CLI=critical limb ischemia; IC=intermittent claudication; Obs=observational; RCT=randomized controlled trial.

This figure shows the forest plot for the primary patency meta-analysis at the 2 to 3 year time point. The result was a summary estimated odds ratio for the four CLI observational studies (CLI-Obs) of 0.77 (95% CI, 0.24 to 2.42, p=0.65); for the two IC-CLI observational studies (IC-CLI-Obs), the summary estimated odds ratio was 0.29 (CI, 0.15 to 0.55, p=0.00); and for the one IC-CLI RCT study (IC-CLI-RCT), the summary estimated odds ratio was 0.96 (CI, 0.42 to 2.16, p=0.92).

The summary estimate for the CLI observational studies (CLI-Obs) was inconclusive, OR 0.77 (95% CI, 0.24 to 2.42, p=0.65). The summary estimate showed a trend toward a benefit of endovascular intervention for the IC-CLI observational studies (IC-CLI-Obs), OR 0.29 (CI, 0.15 to 0.55, p=0.00). The summary estimate did not demonstrate a difference for the IC-CLI RCT study (IC-CLI-RCT), OR 0.96 (CI, 0.42 to 2.16, p=0.92). The forest plot shows the comparisons between the summary estimates by study design and population. The overall SOE was rated insufficient for the CLI and IC-CLI populations on the basis of inconsistent results with wide confidence intervals.

###### Secondary Patency at 1 Year After Enrollment

Figure 33 shows the forest plot for the secondary patency meta-analysis at the 1 year time point. One additional RCT was excluded from this analysis because both the endovascular and surgical groups had 100 percent secondary patency.122 One RCT (fair quality in the IC-CLI population) and four observational studies (three fair and one poor in the CLI population) reporting the rate of secondary patency at 1 year after enrollment.

Figure 33 Forest plot for meta-analysis of secondary patency at 1 year in the CLI and IC-CLI populations

Abbreviations: CI=confidence interval; CLI=critical limb ischemia; IC=intermittent claudication; Obs=observational; RCT=randomized controlled trial.

This figure shows the forest plot for the secondary patency meta-analysis at the 1 year time point. The result was a summary estimated odds ratio for the four CLI observational studies (CLI-Obs) of 0.57 (95% CI, 0.40 to 0.82, p=0.002); and for the one IC-CLI RCT study (IC-CLI-RCT), the summary estimated odds ratio was 0.04 (CI, 0.00 to 0.73, p=0.030).

The summary estimates for the CLI observational studies (CLI-Obs) were OR 0.57 (95% CI, 0.40 to 0.82, p=0.002) and for the IC-CLI RCT study (IC-CLI-RCT), OR 0.04 (CI, 0.00 to 0.73, p=0.03). The forest plot shows the comparisons between the summary estimates by study design and population. The overall SOE was rated low for the CLI population and insufficient for the IC-CLI population.

###### Secondary Patency at 2 to 3 Years After Enrollment

Figure 34 shows the forest plot for this meta-analysis. Four observational studies (three fair and one poor) in the CLI population reporting the rate of secondary patency found that the odds ratio for surgical versus endovascular revascularization was 0.49 (95% CI, 0.28 to 0.85, p=0.01) favoring endovascular revascularization at 2 to 3 years after enrollment. There was evidence of moderate heterogeneity, with a Q-value of 6.13 for 3 degrees of freedom, p=0.10, I^2^=51.10. The overall SOE was rated low on the basis of observational studies with inconsistent results of an indirect outcome and a wide confidence interval.

Figure 34 Forest plot for meta-analysis of secondary patency at 2 to 3 years in the CLI population

Abbreviations: CI=confidence interval; CLI=critical limb ischemia; Obs=observational.

This figure shows the forest plot for the secondary patency meta-analysis at the 2 to 3 year time point. The result was a summary estimated odds ratio for the four CLI observational studies (CLI-Obs) of 0.49 (95% CI, 0.28 to 0.85, p=0.01) favoring endovascular revascularization at 2 to 3 years after enrollment.

###### Effect on Hospital Length of Stay

Fourteen studies (nine in the CLI population and five in the IC-CLI population) reported hospital length of stay during the index hospitalization (Table 27). Some studies reported mean days without standard deviations (SD), and in those studies that did report the SD, the value varied such that we did not consider the data robust enough to calculate a summary estimate of the effect. The range of hospital stay was 1 to 15 days in the endovascular group and 2 to 37 days in the surgical group. Therefore, the SOE was rated insufficient.

Table 27 Endovascular versus surgical revascularization: hospital length of stay

Study Population | Type of Study N Analyzed^a^ Quality | Length of Stay | Results Reported by Authors
Patients with CLI
Adam, 2005^39^ BASIL Study Patients with CLI | RCT N: 452 Good | Days, mean (SD) | Endovascular: 2.06 (1.5) Surgical: 2.14 (1.3)
Ah Chong, 2009^100^ Patients with CLI | Observational N: 464 Poor | Days, mean | Endovascular: 4 Surgical: 24
Faglia, 2012^118^ Patients with CLE | Observational N: 332 Fair | Days, mean (SD) | Endovascular: 5.9 (3.5) Surgical: 10.0 (3.5)
Hynes, 2004^102^ Patients with CLI | Observational N: 137 Fair | Days, mean | Endovascular: 15 Surgical: 37
Jerabek, 2003^103^ Patients with CLI | Observational N: 131 Poor | Days, mean | Endovascular: 9.47 Surgical: 20.69
Kudo, 2006^106^ Patients with CLI | Observational N: 192 (237 limbs) Poor | Days, mean (SD) | Endovascular: 2.6 (4.9) Surgical: 7.7 (8.3)
Loor, 2009^108^ Patients with CLI | Observational N: 92 Fair | Days, mean (SD) | Endovascular: 3.7 (1.3) Surgical: 6.8 (1.3)
Sultan, 2009^109^ Patients with CLI | Observational N: 309 Fair | Days, mean (SD) | Endovascular: 14 (16) Surgical: 24 (23)
Varela, 2011^114^ Patients with CLI | Observational N: 88 (91 limbs) Fair | Days, mean (SD) | Endovascular: 13 (12) Surgical: 19 (14)
Patients with IC or CLI
Dosluoglu, 2010^38^ Patients with IC or CLI | Observational IC: 38% in endovascular arm, 25% in surgical and hybrid arms CLI: 62% in endovascular arm, 75% in surgical and hybrid arms N: 654 Poor | Days, mean (SD) | Endovascular: 3.6 (7.0) Surgical: 9.2 (10.1)
Lepantalo, 2009^123^ Patients with IC or CLI | RCT IC: 87% in endovascular arm, 90% in surgical arm CLI: 13% in endovascular arm, 10% in surgical arm N: 44 Fair | Days, mean (range) | Endovascular: 1.7 (0-7) Surgical: 4.5 (2-10)
McQuade, 2009^124^ Patients with IC or CLI | RCT IC: 82% in endovascular arm, 62% in surgical arm CLI: 18% in endovascular arm, 38% in surgical arm N: 86 Fair | Days, mean (SD) | Endovascular: 0.9 (0.8) Surgical: 3.1 (1.8)
Sachs, 2011^126^ Patients with IC or CLI | Observational IC: NR CLI: NR N: 563,143 Poor | Days, mean (SD) | Endovascular: 1.0 (0.2) Surgical (aortofem): 5.88 (0.31) Surgical (peripheral): 4.52 (0.31)
Whatling, 2000^130^ Patients with IC or CLI | Observational IC: 121 patients of total population CLI: 17 patients of total population N: 138 Poor | Days, mean (SE) | Endovascular: 2.5 (0.6) Surgical: 5.8 (0.6)

a Number of patients in the study arms of interest.

Abbreviations: CLI=critical limb ischemia; IC=intermittent claudication; mo=month/months; RCT=randomized controlled trial; SD=standard deviation; SE=standard error.

#### Modifiers of Effectiveness

Seven studies in the CLI population, including one RCT39 and six observational,104,108,110,112,117,119 reported variations in treatment effectiveness by subgroup (Table 28). All subgroup analyses were performed in studies comparing the effect of endovascular intervention with surgical revascularization. Two studies reported the effect of age.112,117 Two studies reported the effect of treatment based on anatomic factors.104,119 One study reported on the effect of treatment based on the patency of intervention.104 One study reported the effect of treatment based on the presence of tissue loss and the presence of diabetes.108 One study reported the effect of use of autologous vein versus prosthetic bypass material and use of subintimal versus standard angioplasty on amputation-free survival and overall survival.39 One study reported effect of use of autologous versus nonautologous vein grafts.119 We found no studies reporting results by the following subgroups: sex, race, smoking status, or the presence of renal disease. The SOE for modifiers of effectiveness was insufficient given the few number of studies and variety of subgroups that were evaluated.

Table 28 Modifiers of effectiveness for KQ 3

Study Population | Type of Study N Analyzed^a^ Comparison Quality | Subgroup | Results Reported by Authors
Patients with CLI
Adam, 2005^39^ BASIL Study Patients with CLI | RCT N: 452 Endovascular vs. surgical revascularization Good | Patients treated with autologous vein or prosthetic material | Amputation free-survival at 1 yr: Autologous vein: 73% Prosthetic graft: 63% Overall survival at 1 yr: Autologous vein: 79% Prosthetic graft: 78% Amputation free-survival at 2 yr: Autologous vein: 67% Prosthetic graft: 51% Overall survival at 2 yr: Autologous vein: 71% Prosthetic graft: 63% Amputation free-survival at 5 yr: Autologous vein: 47% Prosthetic graft: 19% Overall survival at 5 yr: Autologous vein: 53% Prosthetic graft: 45%
| | Patients treated with subintimal angioplasty vs. standard angioplasty | Amputation free-survival at 1 yr: Subintimal angioplasty: 77% Standard angioplasty: 78% Overall survival at 1 yr: Subintimal angioplasty: 77% Standard angioplasty: 78% Amputation free-survival at 2 yr: Subintimal angioplasty: 64% Standard angioplasty: 66%
| | | Overall survival at 2 yr: Subintimal angioplasty: 64% Standard angioplasty: 66% Amputation free-survival at 5 yr: Subintimal angioplasty: 33% Standard angioplasty: 40% Overall survival at 5 yr: Subintimal angioplasty: 33% Standard angioplasty: 40%
Dosluoglu 2012^119^ Patients with CLI | Observational N: 433 Endovascular vs. surgical revascularization Fair | Patients treated with autologous vein vs. nonautologous vein | Survival at 5 yr: Autologous: 59% Nonautologous: 35% Endovascular: 36% Limb salvage at 5 yr: Autologous: 91% Nonautologous: 67% Endovascular: 78% Amputation-free survival at 5 yr: Autologous: 55% Nonautologous: 25% Endovascular: 30%
Dosluoglu 2012^119^ Patients with CLI | Observational N: 433 Endovascular vs. surgical revascularization Fair | Only patients with TASC-D lesions | Primary patency at 5 yr: Endovascular: 39% Surgical: 47% Autologous vein: 66% Assisted primary patency at 5 yr: Endovascular: 55% Surgical: 58% Autologous vein: 80% Secondary patency at 5 yr: Endovascular: 60% Surgical: 63% Autologous vein: 83% Limb salvage at 5 yr: Endovascular: 77% Surgical: 78% Autologous vein: 91% Amputation-free survival at 5 yr: Endovascular: 29% Autologous vein: 54%
Khan, 2009^104^ Patients with CLI | Observational N: 358 patients, 412 limbs Endovascular vs. surgical revascularization Poor | Anatomy-specific factors Patency of treated segment | Survival at 1 yr: Patients with patent endovascular-treated segment: 67% Patients with patent surgical revascularization bypass(es): 86% Major amputation at 3 mo: Patients with patent endovascular-treated segment: 58% Patients with patent surgical revascularization bypass(es): 36% Major amputation at 12 mo: Patients with patent endovascular-treated segment: 88% Patients with patent surgical revascularization bypass(es): 86%
Loor, 2009^108^ Patients with CLI | Observational N: 92 Endovascular vs. surgical revascularization Fair | Patients with tissue loss | Amputation-free survival at 1 yr: Endovascular: 60% Surgical: 79%
Loor, 2009^108^ Patients with CLI | Observational N: 92 Endovascular vs. surgical revascularization Fair | Presence of diabetes mellitus | Amputation-free survival at 1 yr: Endovascular: 60% Surgical: 79%
Soderstrom, 2010^110^ Patients with CLI | Observational N: 1023 Endovascular vs. surgical revascularization Fair | Presence of diabetes mellitus | Survival at 5 yr: Endovascular: 44.3% Surgical: 39.2% Limb Salvage at 5 yr: Endovascular: 75.3% Surgical: 72.3% Amputation-free Survival at 5 yr: Endovascular: 34.4% Surgical: 32.7% Freedom from any revascularization at 5 yr: Endovascular: 77.8% Surgical: 77.7% Freedom from surgical revascularization at 5 yr: Endovascular: 85.6% Surgical: 93.5%
Taylor, 2005^112^ Patients with CLI | Observational N: 122 Endovascular vs. surgical revascularization Fair | Age: Patients > 80 yr | Mortality at 6 mo: Endovascular: 15.4% Surgical: 3.5% Mortality at 1 yr: Endovascular: 24.9% Surgical: 7.4% Mortality at 2 yr: Endovascular: 32.3% Surgical: 18.9% Mortality at 3 yr: Endovascular: 50.3% Surgical: 26.9% Limb Salvage at 6 mo: Endovascular: 81.4% Surgical: 87.6% Limb Salvage at 1 yr: Endovascular: 77.4% Surgical: 87.6% Limb Salvage at 2 yr: Endovascular: 74.3% Surgical: 82.5% Limb Salvage at 3 yr: Endovascular: 74.3% Surgical: 82.5%
| | | Amputation-free survival at 6 mo: Endovascular: 64.9% Surgical: 84.9% Amputation-free survival at 1 yr: Endovascular: 54.8% Surgical: 79.8% Amputation-free survival at 2 yr: Endovascular: 50.4% Surgical: 71.0% Amputation-free survival at 3 yr: Endovascular: 33.6% Surgical: 63.4% Primary Patency at 6 mo: Endovascular: 68.7% Surgical: 79.9%
| | | Primary Patency at 1 yr: Endovascular: 62.0% Surgical: 67.7% Primary Patency at 2 yr: Endovascular: 55.3% Surgical: 63.3% Primary Patency at 3 yr: Endovascular: 60.5% Surgical: 48.4% Secondary Patency at 6 mo: Endovascular: 80.1% Surgical: 90.4% Secondary Patency at 1 yr: Endovascular: 74.1% Surgical: 87.4% Amputation-free survival at 2 yr: Endovascular: 50.4% Surgical: 71.0% Amputation-free survival at 3 yr: Endovascular: 33.6% Surgical: 63.4%
Zdanowski, 1998^117^ Patients with CLI | Observational N: 4929 Endovascular vs. surgical revascularization Poor | Age: Patients <76 yr and >76 yr | Mortality at 30 days: <76 yr, endovascular: 3.1% <76 yr, surgical: 4.0% >76 yr, endovascular: 6.0% >76 yr, surgical: 6.5% Mortality at 1 yr: <76 yr, endovascular: 17.6% <76 yr, surgical: 17.6% >76 yr, endovascular: 25.8% >76 yr, surgical: 26.6% Amputation-free survival at 30 days: <76 yr, endovascular: 91.5% <76 yr, surgical: 89.3% >76 yr, endovascular: 89.2% >76 yr, surgical: 89.0% Amputation-free survival at 1 yr: <76 yr, endovascular: 73.2% <76 yr, surgical: 72.4% >76 yr, endovascular: 64.1% >76 yr, surgical: 63.2%
Patients with IC or CLI
Dosluoglu, 2010^38^ Patients with IC or CLI | Observational N: 654 Endovascular revascularization vs. surgical revascularization vs. hybrid revascularization Poor | Presence of aortoiliac stenosis | Primary patency at 12 mo Endovascular: 41/45 Surgical: 29/35 Secondary patency at 12 mo Endovascular:41/48 Surgical: 31/35
Hoshino, 2010^121^ Patients with IC or CLI | Observational N: 180 Endovascular revascularization vs. surgical revascularization Fair | Hemodialysis vs. nonhemodialysis | Amputation free survival Hemodialysis: HR 1.69 (0.63-4.99) Nonhemodialysis: HR 1.13 (0.48-2.60) Survival Hemodialysis: HR 2.48 (0.89-8.00) Nonhemodialysis: HR 1.13 (0.48-2.60)
Kashyap, 2008^131^ Patients with IC or CLI | Observational N: 169 Endovascular revascularization vs. surgical revascularization Fair (Unless specified by treatment group, some subgroup findings include the entire study cohort.) | Age | Survival at 3 yr >60 (N=103): 76%, HR 1.0 <60 (N=56): 87%, HR 0.6 (0.3-1.2) Vessel patency >60 Endovascular revascularization (N=91 limbs): 75%, HR 1.0 Surgical revascularization (N=76 limbs): 92% (85-99) HR 1.0 <60 Endovascular revascularization (N=34 limbs): 71%, HR 1.8 (0.8-3.7) Surgical revascularization (N=68 limbs): 94%, HR 0.9 (0.2-3.3)
| | Sex | [underlined: Survival at 3 yr] Male (N=103): 75%, HR 1.0 Female (N=62): 87%, HR 0.7 (0.4-1.3) [underlined: Vessel patency] Male Endovascular revascularization (N=73 limbs): 71%, HR 1.0 Surgical revascularization (N=94 limbs): 93%, HR 1.0 Female Endovascular revascularization (N=52 limbs): 81%, HR 1.8 (0.8-3.7) Surgical revascularization (N=50 limbs): 91%, HR 0.7 (0.2-3.5)
| | Hyperlipidemia | [underlined: Survival at 3 yr] Hyperlipidemia (N=89): 90%, HR 0.4 (0.2-0.8) No hyperlipidemia (N=69): 68%, HR 1.0
| | CAD status | [underlined: Survival at 3 yr] CAD low (N=57): 80%, HR 1.0 CAD intermediate (N=75): 85%, HR 0.9 CAD high (N=27): 66%, HR 1.5 (0.7-3.4)
| | Diabetes | [underlined: Survival at 3 yr] No diabetes (N=124): 83%, HR 1.0 NIDDM (N=29): 72%, HR 2.1 (1.1-4.1) IDDM (N=5): 60%, HR 1.8 (0.4 - 7.7) [underlined: Vessel patency] No diabetes Endovascular revascularization (N=102 limbs): 74%, HR=1.0 Surgical revascularization (N=105 limbs): 95%, HR 1.0 NIDDM Endovascular revascularization (N=21 limbs): 72%, HR 1.5 (0.7-3.5) Surgical revascularization (N=29 limbs): 97%, HR 0.8 (0.1-6.9) IDDM Endovascular revascularization (N=2 limbs): HR 5.3(2.8-10.0) Surgical revascularization (N=8 limbs): 0%, HR 11.6 (3.6-37.6)
| | Hypertension | [underlined: Survival at 3 yr] Hypertension (N=91): 81%, HR 1.1 (0.6-2.1) No hypertension (N=53): 79%, HR 1.0
| | Smoking | [underlined: Survival at 3 yr] Smoking (N=91): 81%, HR 0.9 (0.5-1.7) No smoking (N=53): 83%, HR=1.0 [underlined: Vessel patency] Smoking Endovascular revascularization (N=58 limbs): 75%, HR 0.8 (0.4-1.7) Surgical revascularization (N=102 limbs): 92%, HR 1.2 (0.1-13.9) No smoking Endovascular revascularization (N=65 limbs): 74%, HR 1.0 Surgical revascularization (N=14 limbs): 92%, HR 1.0
| | Renal failure | [underlined: Survival at 3 yr] Renal failure (N=18): 595, HR 2.5 (1.1-5.7) No renal failure (N=141): 83%, HR=1.0
| | Poor outflow | [underlined: Survival at 3 yr] Poor outflow (N=56): 71%, HR 2.0 (1.1-3.7) Good outflow (N=98): 84%, HR 1.0 [underlined: Vessel patency] Poor outflow Endovascular revascularization (N=38 limbs): 66%, HR 1.3 (0.5-3.1) Surgical revascularization (N=56 limbs): 90%, HR 1.3(0.4-4.5) Good outflow Endovascular revascularization (N=85 limbs): 77%, HR 1.0 Surgical revascularization (N=80 limbs): 95%, HR=1.0
| | Claudication vs. rest pain vs. tissue loss vs. ALI | [underlined: Survival at 3 yr] Claudication (N=84): 91%, HR 1.0 Rest pain (N=45): 77%, HR 2.5 (1.1-5.7) Tissue loss (N=19): 63%, HR 8.1 (3.5-18.7) Acute limb ischemia (N=11): 34%, HR 10.5 (4.0-27.7)
| | TASC classification | [underlined: Vessel patency] TASC B Endovascular revascularization (N=20 limbs): 53%, HR 1.0 Surgical revascularization (N=32 limbs): 96%, HR 1.0 TASC C Endovascular revascularization (N=37 limbs): 61%, HR 0.8 (0.3-1.8) Surgical revascularization (N=32 limbs): 91%, HR 0.8 (0.2-3.6) TASC D Endovascular revascularization (N=68 limbs): 90%, HR 0.2 (0.1-0.7) Surgical revascularization (N=32 limbs): 90%, HR 0.4 (0.1-2.7)
| | Femoral management | [underlined: Vessel patency] Native Endovascular revascularization (N=100 limbs): 74%, HR 1.0 Surgical revascularization (N=57 limbs): 95%, HR 1.0 Unilateral common femoral endarterectomy and / or profundaplasty Endovascular revascularization (N=15 limbs): 67%, HR 0.3 (0.1-1.6) Surgical revascularization (N==28 limbs): 100%, HR not estimable Bilateral common femoral endarterectomy and/or profundaplasty Endovascular revascularization (N=4 limbs): Patency not estimable Surgical revascularization (N=46 limbs): 95%, HR 1.2 (0.3 to 5.1) Bypass Endovascular revascularization (N=6 limbs): Patency not estimable, HR 2.4 (0.3 to 20.0) Surgical revascularization (N=11 limbs): 61%, HR 7.4 (1.4 to 38.1)
McQuade, 2009^124^ Kedora, 2007^135^ McQuade, 2010^136^ Patients with IC or CLI | RCT N: 86 Endovascular revascularization vs. surgical revascularization Fair | Stent graft size | [underlined: Vessel patency] Primary patency at 24 mo: Smaller diameter stent graft (5 mm): 54% Larger diameter stent graft (6-7 mm): 69% Surgical bypass: 64% Primary patency at 48 mo: Smaller diameter stent graft (5 mm): 54% Larger diameter stent graft (6-7 mm): 62% Surgical bypass: 58% Secondary patency at 24 mo: Smaller diameter stent graft (5 mm): 70% Larger diameter stent graft (6-7 mm): 77% Surgical bypass: 76% Secondary patency at 48 mo: Smaller diameter stent graft (5 mm): 70% Larger diameter stent graft (6-7 mm): 77% Surgical bypass: 71%
Sachs, 2011^126^ Patients with IC or CLI | Observational N: 563,143 Endovascular revascularization vs. surgical revascularization Poor | CLI | [underlined: In-hospital mortality] Endovascular revascularization: 2.1% Aortofemoral bypass: 4.1% Peripheral bypass: 2.6% [underlined: Major amputation] Endovascular revascularization: 7.0% Aortofemoral bypass: 3.0% Peripheral bypass: 3.9%
Stoner, 2008^127^ Patients with IC or CLI | Observational N: 359 Endovascular revascularization vs. surgical revascularization Poor | IC vs. CLI | [underlined: Vessel patency] Primary assisted patency at 12 mo IC Endovascular revascularization: 80% +/- 0.04% Surgical revascularization 93% +/- 0.03% CLI Endovascular revascularization: 54% +/- 0.05% Surgical revascularization: 66% +/- 0.05%
Timaran, 2003^128^ Patients with IC or CLI | Observational N: 188 Endovascular revascularization vs. surgical revascularization Fair | Patients with poor run-off | [underlined: Vessel patency] Primary patency at 1 yr Endovascular revascularization: 74% Surgical revascularization: 80% Primary patency at 3 yr Endovascular revascularization: 36% Surgical revascularization: 75% Primary patency at 5 yr Endovascular revascularization: 36% Surgical revascularization: 68%

a Number of patients in the study arms of interest.

Abbreviations: CLI=critical limb ischemia; IC=intermittent claudication; mo=month/months; PAD=peripheral artery disease; yr=year/years.

In the mixed IC-CLI population, seven studies, including one RCT124 and six observational studies38,121,126-128,131 reported variations in treatment effectiveness by subgroup (Table 28). All subgroup analyses were performed in studies comparing the effect of endovascular intervention with surgical revascularization. Three studies reported the effect of symptom class.126,127,131 Two studies reported the effect of renal failure.121,131 Two studies reported the effect of arterial outflow or runoff.128,131 One study reported the effect of age, sex, smoking status, presence of hyperlipidemia, coronary artery disease, diabetes mellitus, hypertension,131 anatomic location of stenosis,131 and stent graft size.124

We found no studies reporting results by the following subgroups: patency of intervention or type of conduit (autologous vein or prosthetic material). The SOE for modifiers of effectiveness was insufficient for the other modifiers given the small number of studies and variety of subgroups that were evaluated.

In the single RCT of CLI patients, the use of autologous vein was associated with improved outcomes when compared with prosthetic conduit. Additionally, the performance of subintimal angioplasty was associated with statistically nonsignificant worse outcomes when compared with standard angioplasty. Data derived from the observational studies had a high likelihood of bias but did show that with advanced age, renal failure, and higher Rutherford classification, patients generally fared worse in terms of mortality and amputation.

#### Safety Concerns

In the CLI population, one observational study (fair quality)101 reported safety concerns. Specifically, this study reported the incidence of thrombosis at 30 days and found that the risk of thrombosis was higher in patients undergoing surgical revascularization than in patients undergoing endovascular revascularization.

We found no studies in this population reporting harms of adverse drug reactions, bleeding, contrast nephropathy, radiation, infection, or periprocedural complications causing acute limb ischemia. The SOE for harms was insufficient given the small number of studies reporting this outcome. It may be that treatment harms are not routinely documented or collected in retrospective or prospective observational studies.

In the IC-CLI population, six studies including two RCTs123,124 and four observational studies38,122,125,131 reported safety concerns. Six studies38,122-125,131 reported the incidence of periprocedural complications in patients undergoing endovascular and surgical revascularization. Three studies38,123,131 reported the incidence of infection, one study38 reported the incidence of bleeding, and one study131 reported the incidence of renal dysfunction following endovascular and surgical revascularization (Table 29).

Table 29 Safety concerns in the IC-CLI population

Study | Type of Study N Analyzed^a^ Comparison Quality | Harm | Results Reported by Authors
Patients with IC or CLI
Dosluoglu, 2010^38^ | Observational N: 654 Endovascular revascularization vs. surgical revascularization vs. hybrid revascularization Poor | 1. Bleeding; 2. Infection; 3. Periprocedural complications (graft/stent occlusion) | 1. Endovascular: 0.2%; Surgical: 1.3%; 2. Endovascular: 0.2%; Surgical: 15.4%; 3. Endovascular: 0.5%; Surgical: 1.8%
Janne d'Othee, 2008^122^ | Observational N: 97 Endovascular vs. surgical revascularization Fair | 1. Periprocedural complications (complications requiring medical care within 30 days) | Endovascular: 0.5% Surgical: 1.8%
Kashyap, 2008^131^ | Observational N: 169 Endovascular revascularization vs. surgical revascularization Fair | 1. Renal dysfunction; 2. Infection; 3. Periprocedural complications (no definition given) | 1. Endovascular: 4.8%; Surgical: 1.1%; 2. Endovascular: 2.4%; Surgical: 5.8%; 3. Endovascular: 0%; Surgical: 3.5%
Lepantalo, 2009^123^ | RCT N: 44 Endovascular vs. surgical revascularization Fair | 1. Infection; 2. Periprocedural complications (graft/stent occlusion) | 1. Endovascular: 0%; Surgical: 19.0%; 2. Endovascular: 8.7%; Surgical: 0%
McQuade, 2009^124^ Kedora, 2007^135^ McQuade, 2010^136^ | RCT N: 86 Endovascular revascularization vs. surgical revascularization Fair | Periprocedural complications (vascular dissection, leg edema, thigh pain) | Endovascular: 8.0% Surgical: 6.0%
Rossi, 1998^125^ | Observational N: 48 Endovascular vs. surgical revascularization Poor | Periprocedural complications (cardiac event) | Endovascular: 16.2% Surgical: 45.5%

a Number of patients in the study arms of interest.

Abbreviation: RCT=randomized controlled trial.

##### Periprocedural Complications by 30 Days

Figure 35 shows the forest plot for the meta-analysis of the two RCTs123,124 and four observational studies38,122,125,131 comparing the effect of surgical revascularization versus endovascular revascularization on periprocedural complications by 30 days in IC-CLI patients. Periprocedural complications may have included graft or stent occlusion, limb ischemia, wound dehiscence, arterial dissection or any repeat revascularization procedure.

Figure 35 Forest plot for meta-analysis of surgical versus endovascular revascularization on periprocedural complications by 30 days in IC-CLI population

Abbreviations: CI=confidence interval; CLI=critical limb ischemia; IC=intermittent claudication; Obs=observational; RCT=randomized controlled trial.

This figure shows the forest plot for the meta-analysis of the two RCTs and four observational studies comparing the effect of surgical revascularization versus endovascular revascularization on periprocedural complications by 30 days in IC-CLI patients. The results was a summary estimated odds ratio for the four observational studies of 1.87 (95% CI, 0.63 to 5.49, p=0.26) favoring the endovascular strategy; and for the two RCT studies, the summary estimated odds ratio was 0.57 (CI, 0.14 to 2.26, p=0.42) favoring a surgical strategy. The overall summary estimated odds ratio was 1.19 (CI, 0.51 to 2.79, p=0.69).

In the observational studies, the between-group estimate was OR 1.87 (95% CI, 0.63 to 5.49) favoring the endovascular strategy; however, in the RCTs the estimated odds ratio was 0.57 (CI, 0.14 to 2.26) favoring a surgical strategy, both being considered inconclusive in their findings. The differences in results between the observational studies and RCTs may be due to the types of periprocedural complications reported and the definition of those complications across studies. Patient selection bias in the observational studies is likely a factor where healthier patients (higher proportion of IC patients) are chosen for an endovascular procedure, whereas in the RCTs the distribution of PAD severity would have been equally distributed. The SOE is insufficient given the high number of observational studies and two fair-quality RCTs, inconsistent results, differing definitions of a periprocedural complication, and imprecise results.

##### Infection by 30 Days

Figure 36 shows the forest plot for the meta-analysis of the three studies38,123,131 (one fair-quality RCT; two observational studies, one fair, one poor) comparing surgical versus endovascular revascularization on periprocedural complications by 30 days in IC-CLI patients.

Figure 36 Forest plot for meta-analysis of surgical versus endovascular revascularization on infections by 30 days in IC-CLI population

Abbreviations: CI=confidence interval; CLI=critical limb ischemia; IC=intermittent claudication; Obs=observational; RCT=randomized controlled trial.

This figure shows the forest plot for the meta-analysis of the three studies comparing surgical versus endovascular revascularization on periprocedural complications by 30 days in IC-CLI patients. In the observational studies, the between-group estimate was OR 14.10 (95% CI, 0.43 to 460.70, p=0.14), and in the RCT the estimated OR was 12.09 (CI, 0.61 to 239.54, p=0.10) with both favoring an endovascular strategy. The overall estimated OR was 12.90 (CI, 1.34 to 124.65, p=0.03).

In the observational studies, the between-group estimate was OR 14.10 (95% CI, 0.43 to 460.70), and in the RCT the estimated OR was 12.09 (CI, 0.61 to 239.54) with both favoring an endovascular strategy although not reaching statistical significance. The overall estimated OR was 12.90 (CI, 1.34 to 124.65). There was some evidence of heterogeneity, with a Q-value of 5.52 for 2 degrees of freedom, p=0.06; I^2^=63.78. The heterogeneity is likely due to the patient selection bias in the observational studies, although it is plausible that surgical revascularization will cause more wound infections when compared to endovascular intervention. Given the small number of studies, moderate heterogeneity, and imprecision, the SOE is low.

Also, in the IC-CLI population, we found no studies reporting harms of adverse drug reactions and radiation. The SOE for the remaining safety concerns was insufficient given the small number of studies reporting these outcomes. It may be that treatment harms are not routinely documented or collected in retrospective or prospective observational studies.

### SOE Ratings for KQ 3

Tables 30–31 summarize the SOE for the outcomes across the four domains outlined in the KQ by each treatment comparison. Any outcomes not reported in either the CLI or IC-CLI population are grouped together and labeled as insufficient evidence. The tables list outcomes for the type of PAD population and study design if they are reported in the literature; therefore assume that any PAD population or study design not listed under that outcome constitutes no (or insufficient) evidence.

Table 30 Detailed SOE for endovascular intervention versus usual care in CLI and IC-CLI populations

Population Study Design Number of Studies (Total Patients) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect Effect Estimate (95% CI)
All-cause mortality
CLI Observational 3 (562) | 2 moderate risk, 1 high risk | Consistent | Direct | Imprecise | Mortality higher in usual care group when compared with endovascular group Insufficient SOE
IC-CLI Observational 1 (107) | 1 moderate risk | NA | Direct | Imprecise | Endovascular intervention: 5.5% Usual care: 5.8% Insufficient SOE
Amputation
CLI Observational 3 (562) | 2 moderate risk, 1 high risk | Inconsistent | Direct | Imprecise | Amputation rate was higher in usual care group in two studies, and it was only reported in the revascularization group in the other study Insufficient SOE
IC-CLI Observational 1 (107) | 1 moderate risk | NA | Direct | Imprecise | Endovascular intervention: 5.5% Usual care: 3.8% Insufficient SOE
Amputation-free survival
CLI Observational 1 (70) | 1 high risk | NA | Direct | Imprecise | Amputation-free survival was better in endovascular group (60% vs. 47%) Insufficient SOE
Length of stay
CLI Observational 3 (562) | 2 moderate risk, 1 high risk | Inconsistent | Indirect | Imprecise | LOS was lower in the endovascular group in two studies, and it was only reported in the revascularization group in the other study Insufficient SOE
Nonfatal stroke Nonfatal MI Composite cardiovascular events MWD or ACD Initial claudication distance or pain-free walking distance Quality of life Primary patency Secondary patency Wound healing Analog pain scale Modifiers of effectiveness (subgroups) Safety concerns Safety concerns (subgroups)
All 0 | NA | NA | NA | NA | Insufficient SOE

Abbreviations: ACD=absolute claudication distance; CI=confidence interval; CLI=critical limb ischemia; IC=intermittent claudication; LOS=hospital length of stay; MI=myocardial infarction; MWD=masimal walking distance; NA=not applicable; RCT=randomized controlled trial; SOE=strength of evidence.

Table 31 Detailed SOE of evidence for endovascular versus surgical revascularization in CLI and IC-CLI populations

Population | Study Design Number of Studies (Total Patients) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect Effect Estimate (95% CI)
All-cause mortality ≤6 mo
CLI | Observational: 11 (8249) RCT: 1 (452) | Observational: 1 low risk, 6 moderate risk, 4 high risk RCT: 1 low risk | Inconsistent | Direct | Imprecise | Observational OR 0.85 (0.57 to 1.27) RCT OR 0.51 (0.20 to 1.35) Favors endovascular Low SOE
IC-CLI | Observational: 2 (823) | 1 moderate risk, 1 high risk | Consistent | Direct | Imprecise | OR 0.45 (0.18 to 1.09) Favors endovascular Low SOE
All-cause mortality at 1–2 yr
CLI | Observational: 12 (7850) | 1 low risk, 8 moderate risk, 3 high risk | Consistent | Direct | Imprecise | OR 1.01 (0.80 to 1.28) No difference Low SOE
IC-CLI | Observational: 2 (145) RCT: 2 (130) | Observational: 1 moderate risk, 1 high risk RCT: 2 moderate risk | Inconsistent | Direct | Imprecise | Observational OR 0.51 (0.20 to 1.31) RCT OR 0.81 (0.23 to 2.82) Favors endovascular Low SOE
All-cause mortality at ≥3 yr
CLI | Observational: 7 (7176) RCT: 1 (452) | Observational: 1 low risk, 3 moderate risk, 3 high risk RCT: 1 low risk | Inconsistent | Direct | Imprecise | Observational: OR 1.05 (0.54 to 2.06) RCT: OR 1.07 (0.73 to 1.56) No difference Low SOE
IC-CLI | RCT: 1 (58) | 1 moderate risk | NA | Direct | Imprecise | OR 0.88 (0.28 to 2.73) Inconclusive Insufficient SOE
Nonfatal MI
CLI | RCT: 1 (452) | 1 low risk | NA | Direct | Imprecise | Endovascular group had fewer MIs than surgical group (3% vs. 8%) Insufficient SOE
Amputation at <2 yr
CLI | Observational: 11 (4490) RCT: 1 (452) | Observational: 1 low risk, 6 moderate risk, 4 high risk RCT: 1 low risk | Inconsistent | Direct | Imprecise | Observational: OR 0.73 (0.48 to 1.09) RCT OR 1.23 (0.72 to 2.11) No difference Low SOE
IC-CLI | Observational: 2 (823) RCT: 2 (130) | Observational: 1 moderate risk, 1 high risk RCT: 2 moderate risk | Inconsistent | Direct | Imprecise | Observational OR 1.11 (0.40 to 3.05) RCT OR 0.22 (0.05 to 1.07) Inconclusive Insufficient SOE
Amputation at 2–3 yr
CLI | Observational: 4 (3187) RCT: 1 (452) | Observational: 1 low risk, 2 moderate risk, 1 high risk RCT: 1 low risk | Inconsistent | Direct | Imprecise | Observational OR 1.08 (0.62 to 1.89) RCT OR 1.02 (0.64 to 1.63) No difference Low SOE
IC-CLI | Observational: 1 (169) RCT: 1 (86) | Observational: 1 moderate risk RCT: 1 moderate risk | Inconsistent | Direct | Imprecise | Observational OR 1.00 (0.18 to 5.54) RCT OR 0.18 (0.03 to 1.29) Inconclusive Insufficient SOE
Amputation after 5 yr
CLI | Observational: 7 (3101) | 1 low risk, 3 moderate risk, 3 high risk | Inconsistent | Direct | Imprecise | OR 1.06 (0.70 to 1.59) No difference Low SOE
Amputation-free survival at 1 yr
CLI | Observational: 2 (1881) RCT: 1 (452) | Observational: 1 low risk, 1 moderate risk RCT: 1 low risk | Consistent | Direct | Precise | Observational OR 0.76 (0.48 to 1.21) RCT OR 0.87 (0.58 to 1.30) No difference Low SOE
Amputation-free survival at 2–3 yr
CLI | Observational: 3 (1972) RCT: 1 (452) | Observational: 1 low risk, 2 moderate risk RCT: 1 low risk | Inconsistent | Direct | Imprecise | Observational OR 0.76 (0.53 to 1.09) RCT OR 1.22 (0.84 to 1.77) No difference Low SOE
Amputation-free survival after 5 yr
CLI | Observational: 4 (2190) | 1 low risk, 3 moderate risk | Inconsistent | Direct | Imprecise | OR 0.89 (0.59 to 1.34) No difference Low SOE
Wound healing
CLI | Observational: 1 (91) | 1 moderate risk | NA | Indirect | Imprecise | Surgical revascularization (83%) endovascular revascularization (80%) Insufficient SOE
Primary patency at 1 yr
CLI | Observational: 5 (890) | 3 moderate risk, 2 high risk | Consistent | Indirect | Precise | OR 0.63 (0.46 to 0.86) No difference Moderate SOE
IC-CLI | Observational: 3 (328) RCT: 2 (130) | Observational: 3 moderate risk RCT: 2 moderate risk | Consistent | Indirect | Imprecise | Observational OR 0.71 (0.40 to 1.28) RCT OR 0.40 (0.08 to 1.93) Favors endovascular Low SOE
Primary patency at 2–3 yr
CLI | Observational: 4 (768) | 3 moderate risk, 1 high risk | Inconsistent | Indirect | Imprecise | OR 0.77 (0.24 to 2.42) Inconclusive Insufficient SOE
IC-CLI | Observational: 2 (231) RCT: 1 (86) | Observational: 2 moderate risk RCT: 1 moderate risk | Inconsistent | Indirect | Imprecise | Observational OR 0.29 (0.15 to 0.55) RCT OR 0.96 (0.42 to 2.16) Inconclusive Insufficient SOE
Secondary patency at 1 yr
CLI | Observational: 4 (759) | 3 moderate risk, 1 high risk | Inconsistent | Indirect | Imprecise | OR 0.57 (0.40 to 0.82) Favors endovascular Low SOE
IC-CLI | RCT: 1 (44) | 1 moderate risk | NA | Indirect | Imprecise | OR 0.04 (0.00 to 0.73) Inconclusive Insufficient SOE
Secondary patency at 2–3 yr
CLI | Observational: 4 (815) | 3 moderate risk, 1 high risk | Inconsistent | Indirect | Imprecise | OR 0.49 (0.28 to 0.85) Favors endovascular Low SOE
Length of stay
CLI | Observational: 8 (1745) RCT: 1 (452) | Observational: 5 moderate risk, 3 high risk RCT: 1 low risk | Inconsistent | Indirect | Imprecise | LOS longer in surgical group with large SD in 3 observational studies and no variability reported in 4 observational studies and one RCT Insufficient SOE
IC-CLI | Observational: 3 (563,935) RCT: 2 (130) | Observational: 3 high risk RCT: 2 moderate risk | Consistent | Indirect | Imprecise | LOS longer in surgical group with large SD in the observational studies and RCTs Insufficient SOE
Modifiers of effectiveness (subgroups)
All | 2 RCTs, 12 observational (572,188) | 1 low risk, 8 moderate risk, 5 high risk | NA | NA | NA | One RCT showed higher survival in autologous vein graft compared to prosthetic graft. An observational study showed worse survival in advanced age, renal failure and with higher PAD severity. Insufficient SOE
Safety concerns: periprocedural complications
IC-CLI | Observational: 4 (968) RCT: 2 (130) | Observational: 2 moderate risk, 2 high risk RCT: 2 moderate risk | Inconsistent | Direct | Imprecise | Observational OR 1.87 (0.63 to 5.49) RCT OR 0.57 (0.14 to 2.26) Observational studies favored endovascular while the RCTs favored surgical revascularization Insufficient SOE
Safety concerns: infection
IC-CLI | Observational: 2 (823) RCT: 1 (44) | Observational: 1 moderate risk, 1 high risk RCT: 1 moderate risk | Consistent | Direct | Imprecise | Observational OR 14.10 (0.43 to 460.70) RCT OR 12.09 (0.61 to 239.54) Favors endovascular Low SOE
Nonfatal stroke Composite cardiovascular events MWD or ACD ICD or PFWD Quality of life Analog pain scale Safety concerns (subgroups)
All | 0 | NA | NA | NA | NA | Insufficient SOE

Abbreviations: ACD=absolute claudication distance; CI=confidence interval; CLI=critical limb ischemia; IC=intermittent claudication; ICD=initial claudication distance; LOS=hospital length of stay; MI=myocardial infarction; MWD=maximal walking distance; NA=not applicable; Obs=observational; PFWD=pain-free walking distance; RCT=randomized controlled trial; SOE=strength of evidence.