# References

1 Hiatt WR, Goldstone J, Smith SC Jr., et al. Atherosclerotic Peripheral Vascular Disease Symposium II: nomenclature for vascular diseases. Circulation. 2008;118(25):2826-9. [pmid: 19106403].
2 Hirsch AT, Haskal ZJ, Hertzer NR, et al. ACC/AHA 2005 Practice Guidelines for the management of patients with peripheral arterial disease (lower extremity, renal, mesenteric, and abdominal aortic): a collaborative report from the American Association for Vascular Surgery/Society for Vascular Surgery, Society for Cardiovascular Angiography and Interventions, Society for Vascular Medicine and Biology, Society of Interventional Radiology, and the ACC/AHA Task Force on Practice Guidelines (Writing Committee to Develop Guidelines for the Management of Patients With Peripheral Arterial Disease): endorsed by the American Association of Cardiovascular and Pulmonary Rehabilitation; National Heart, Lung, and Blood Institute; Society for Vascular Nursing; TransAtlantic Inter-Society Consensus; and Vascular Disease Foundation. Circulation. 2006;113(11):e463-654. [pmid: 16549646].
3 Hirsch AT, Criqui MH, Treat-Jacobson D, et al. Peripheral arterial disease detection, awareness, and treatment in primary care. JAMA. 2001;286(11):1317-24. [pmid: 11560536].
4 Meijer WT, Hoes AW, Rutgers D, et al. Peripheral arterial disease in the elderly: The Rotterdam Study. Arterioscler Thromb Vasc Biol. 1998;18(2):185-92. [pmid: 9484982].
5 Hiatt WR. Medical treatment of peripheral arterial disease and claudication. N Engl J Med. 2001;344(21):1608-21. [pmid: 11372014].
6 Norgren L, Hiatt WR, Dormandy JA, et al. Inter-Society Consensus for the Management of Peripheral Arterial Disease (TASC II). European Journal of Vascular and Endovascular Surgery. Suppl 1. 2007;33:S1-75. [pmid: 17140820].
7 Criqui MH, Ninomiya JK, Wingard DL, et al. Progression of peripheral arterial disease predicts cardiovascular disease morbidity and mortality. Journal of the American College of Cardiology. 2008;52(21):1736-42. [pmid: 19007695].
8 Criqui MH, Langer RD, Fronek A, et al. Mortality over a period of 10 years in patients with peripheral arterial disease. New England Journal of Medicine. 1992;326(6):381-6. [pmid: 1729621].
9 Remes L, Isoaho R, Vahlberg T, et al. Quality of life among lower extremity peripheral arterial disease patients who have undergone endovascular or surgical revascularization: a case-control study. European Journal of Vascular and Endovascular Surgery. 2010;40(5):618-25. [pmid: 20418121].
10 Nehler MR, McDermott MM, Treat-Jacobson D, et al. Functional outcomes and quality of life in peripheral arterial disease: current status. Vascular Medicine. 2003;8(2):115-26. [pmid: 14518614].
11 Kannel WB. Risk factors for atherosclerotic cardiovascular outcomes in different arterial territories. Journal of Cardiovascular Risk. 1994;1(4):333-9. [pmid: 7621317].
12 Rooke TW, Hirsch AT, Misra S, et al. 2011 ACCF/AHA focused update of the guideline for the management of patients with peripheral artery disease (updating the 2005 guideline): a report of the American College of Cardiology Foundation/American Heart Association Task Force on Practice Guidelines: developed in collaboration with the Society for Cardiovascular Angiography and Interventions, Society of Interventional Radiology, Society for Vascular Medicine, and Society for Vascular Surgery. J Vasc Surg. 2011;54(5):e32-58. [pmid: 21958560].
13 Resnick HE, Lindsay RS, McDermott MM, et al. Relationship of high and low ankle brachial index to all-cause and cardiovascular disease mortality: the Strong Heart Study. Circulation. 2004;109(6):733-9. [pmid: 14970108].
14 Mehler PS, Coll JR, Estacio R, et al. Intensive blood pressure control reduces the risk of cardiovascular events in patients with peripheral arterial disease and type 2 diabetes. Circulation. 2003;107(5):753-6. [pmid: 12578880].
15 Ware JE Jr., Sherbourne CD. The MOS 36-item short-form health survey (SF-36). I. Conceptual framework and item selection. Med Care. 1992;30(6):473-83. [pmid: 1593914].
16 Spronk S, Bosch JL, den Hoed PT, et al. Intermittent claudication: clinical effectiveness of endovascular revascularization versus supervised hospital-based exercise training--randomized controlled trial. Radiology. 2009;250(2):586-95. [pmid: 19188327].
17 Dolan P. Modeling valuations for EuroQol health states. Med Care. 1997;35(11):1095-108. [pmid: 9366889].
18 Morgan MB, Crayford T, Murrin B, et al. Developing the Vascular Quality of Life Questionnaire: a new disease-specific quality of life measure for use in lower limb ischemia. J Vasc Surg. 2001;33(4):679-87. [pmid: 11296317].
19 McDermott MM, Liu K, Guralnik JM, et al. Measurement of walking endurance and walking velocity with questionnaire: validation of the walking impairment questionnaire in men and women with peripheral arterial disease. J Vasc Surg. 1998;28(6):1072-81. [pmid: 9845659].
20 Spertus J, Jones P, Poler S, et al. The peripheral artery questionnaire: a new disease-specific health status measure for patients with peripheral arterial disease. Am Heart J. 2004;147(2):301-8. [pmid: 14760329].
21 Bernardi D, Bartoli P, Ferreri A, et al. Assessment of captopril and nicardipine effects on chronic occlusive arterial disease of the lower extremity using Doppler ultrasound. Angiology. 1988;39(11):942-52. [pmid: 3052183].
22 Roberts DH, Tsao Y, McLoughlin GA, et al. Placebo-controlled comparison of captopril, atenolol, labetalol, and pindolol in hypertension complicated by intermittent claudication. Lancet. 1987;2(8560):650-3. [pmid: 2887941].
23 Van de Ven LL, Van Leeuwen JT, Smit AJ. The influence of chronic treatment with betablockade and angiotensin converting enzyme inhibition on the peripheral blood flow in hypertensive patients with and without concomitant intermittent claudication. A comparative cross-over trial. Vasa. 1994;23(4):357-62. [pmid: 7817618].
24 Giri J, McDermott MM, Greenland P, et al. Statin use and functional decline in patients with and without peripheral arterial disease. Journal of the American College of Cardiology. 2006;47(5):998-1004. [pmid: 16516084].
25 Dawson DL, Cutler BS, Hiatt WR, et al. A comparison of cilostazol and pentoxifylline for treating intermittent claudication. Am J Med. 2000;109(7):523-30. [pmid: 11063952].
26 McDermott MM, Ades P, Guralnik JM, et al. Treadmill exercise and resistance training in patients with peripheral arterial disease with and without intermittent claudication: a randomized controlled trial. JAMA. 2009;301(2):165-74. [pmid: 19141764].
27 Liao JK, Bettmann MA, Sandor T, et al. Differential impairment of vasodilator responsiveness of peripheral resistance and conduit vessels in humans with atherosclerosis. Circ Res. 1991;68(4):1027-34. [pmid: 2009605].
28 Fronek A, DiTomasso DG, Allison M. Noninvasive assessment of endothelial activity in patients with peripheral arterial disease and cardiovascular risk factors. Endothelium. 2007;14(4-5):199-205. [pmid: 17922336].
29 Yataco AR, Corretti MC, Gardner AW, et al. Endothelial reactivity and cardiac risk factors in older patients with peripheral arterial disease. Am J Cardiol. 1999;83(5):754-8. [pmid: 10080432].
30 McDermott MM, Guralnik JM, Ferrucci L, et al. Asymptomatic peripheral arterial disease is associated with more adverse lower extremity characteristics than intermittent claudication. Circulation. 2008;117(19):2484-91. [pmid: 18458172].
31 McDermott MM, Hoff F, Ferrucci L, et al. Lower extremity ischemia, calf skeletal muscle characteristics, and functional impairment in peripheral arterial disease. J Am Geriatr Soc. 2007;55(3):400-6. [pmid: 17341243].
32 Hiatt WR, Regensteiner JG, Wolfel EE, et al. Effect of exercise training on skeletal muscle histology and metabolism in peripheral arterial disease. J Appl Physiol. 1996;81(2):780-8. [pmid: 8872646].
33 Hiatt WR, Wolfel EE, Regensteiner JG, et al. Skeletal muscle carnitine metabolism in patients with unilateral peripheral arterial disease. J Appl Physiol. 1992;73(1):346-53. [pmid: 1506390].
34 Pipinos II, Sharov VG, Shepard AD, et al. Abnormal mitochondrial respiration in skeletal muscle in patients with peripheral arterial disease. J Vasc Surg. 2003;38(4):827-32. [pmid: 14560237].
35 Pipinos II, Judge AR, Zhu Z, et al. Mitochondrial defects and oxidative damage in patients with peripheral arterial disease. Free Radic Biol Med. 2006;41(2):262-9. [pmid: 16814106].
36 Schmieder FA, Comerota AJ. Intermittent claudication: magnitude of the problem, patient evaluation, and therapeutic strategies. Am J Cardiol. 2001;87(12A):3D-13D. [pmid: 11434894].
37 Jaff MR, Cahill KE, Yu AP, et al. Clinical outcomes and medical care costs among medicare beneficiaries receiving therapy for peripheral arterial disease. Annals of Vascular Surgery. 2010;24(5):577-87. [pmid: 20579582].
38 Dosluoglu HH, Lall P, Cherr GS, et al. Role of simple and complex hybrid revascularization procedures for symptomatic lower extremity occlusive disease. J Vasc Surg. 2010;51(6):1425-1435 e1. [pmid: 20488323].
39 Adam DJ, Beard JD, Cleveland T, et al. Bypass versus angioplasty in severe ischaemia of the leg (BASIL): multicentre, randomised controlled trial. Lancet. 2005;366(9501):1925-34. [pmid: 16325694].
40 Conte MS, Bandyk DF, Clowes AW, et al. Results of PREVENT III: a multicenter, randomized trial of edifoligide for the prevention of vein graft failure in lower extremity bypass surgery. J Vasc Surg. 2006;43(4):742-751. discussion 751. [pmid: 16616230].
41 Goodney PP, Schanzer A, Demartino RR, et al. Validation of the Society for Vascular Surgery's objective performance goals for critical limb ischemia in everyday vascular surgery practice. J Vasc Surg. 2011;54(1):100-108 e4. [pmid: 21334173].
42 Abou-Zamzam AM Jr., Gomez NR, Molkara A, et al. A prospective analysis of critical limb ischemia: factors leading to major primary amputation versus revascularization. Ann Vasc Surg. 2007;21(4):458-63. [pmid: 17499967].
43 Feinglass J, Sohn MW, Rodriguez H, et al. Perioperative outcomes and amputation-free survival after lower extremity bypass surgery in California hospitals, 1996-1999, with follow-up through 2004. J Vasc Surg. 2009;50(4):776-783 e1. [pmid: 19595538].
44 Berger JS, Krantz MJ, Kittelson JM, et al. Aspirin for the prevention of cardiovascular events in patients with peripheral artery disease: a meta-analysis of randomized trials. JAMA. 2009;301(18):1909-19. [pmid: 19436018].
45 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=318. March 16, 2012.
46 Moher D, Liberati A, Tetzlaff J, et al., The PRISMA Group. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. PLo S Med. 2009;6(7):e1000097. [pmid: 19621072].
47 Evidence-based Practice Center Systematic Review Protocol. Project Title: Treatment Strategies for Patients With Peripheral Artery Disease. January. 31. 2012. http://effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?productid=948&pageaction=displayproduct. November 19, 2012.
48 Cohen J. Statistical Power Analysis for the Behavioral Sciences. 2nd ed. Hillsdale, N.J. L. Erlbaum Associates. 1988.
49 Beebe HG, Dawson DL, Cutler BS, et al. A new pharmacological treatment for intermittent claudication: results of a randomized, multicenter trial. Arch Intern Med. 1999;159(17):2041-50. [pmid: 10510990].
50 Hasselblad V. Meta-analysis of multitreatment studies. Med Decis Making. 1998;18(1):37-43. [pmid: 9456207].
51 Soga Y, Yokoi H, Kawasaki T, et al. Efficacy of cilostazol after endovascular therapy for femoropopliteal artery disease in patients with intermittent claudication. J Am Coll Cardiol. 2009;53(1):48-53. [pmid: 19118724].
52 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--Agency for Healthcare Research and Quality and the Effective Health-Care Program. J Clin Epidemiol. 2010;63(5):513-23. [pmid: 19595577].
53 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. 2011;64(11):1198-207. [pmid: 21463926].
54 Belch J, MacCuish A, Campbell I, et al. The prevention of progression of arterial disease and diabetes (POPADAD) trial: factorial randomised placebo controlled trial of aspirin and antioxidants in patients with diabetes and asymptomatic peripheral arterial disease. BMJ. 2008;337:a1840. [pmid: 18927173].
55 Catalano M, Born G, Peto R. Prevention of serious vascular events by aspirin amongst patients with peripheral arterial disease: randomized, double-blind trial. J Intern Med. 2007;261(3):276-84. [pmid: 17305650].
56 Fowkes FG, Price JF, Stewart MC, et al. Aspirin for prevention of cardiovascular events in a general population screened for a low ankle brachial index: a randomized controlled trial. JAMA. 2010;303(9):841-8. [pmid: 20197530].
57 Mahmood A, Sintler M, Edwards AT, et al. The efficacy of aspirin in patients undergoing infra-inguinal bypass and identification of high risk patients. Int Angiol. 2003;22(3):302-7. [pmid: 14612858].
58 Minar E, Ahmadi A, Koppensteiner R, et al. Comparison of effects of high-dose and low-dose aspirin on restenosis after femoropopliteal percutaneous transluminal angioplasty. Circulation. 1995;91(8):2167-73. [pmid: 7697845].
59 A randomised, blinded trial of clopidogrel versus aspirin in patients at risk of ischaemic events (CAPRIE). Lancet. 1996;348(9038):1329-39. [pmid: 8918275].
60 Cacoub PP, Bhatt DL, Steg PG, et al. Patients with peripheral arterial disease in the CHARISMA trial. Eur Heart J. 2009;30(2):192-201. [pmid: 19136484].
61 Cassar K, Ford I, Greaves M, et al. Randomized clinical trial of the antiplatelet effects of aspirin-clopidogrel combination versus aspirin alone after lower limb angioplasty. Br J Surg. 2005;92(2):159-65. [pmid: 15609386].
62 Horrocks M, Horrocks EH, Murphy P, et al. The effects of platelet inhibitors on platelet uptake and restenosis after femoral angioplasty. Int Angiol. 1997;(2):101-6. [pmid: 9257670].
63 Belch JJ, Dormandy J, Biasi GM, et al. Results of the randomized, placebo-controlled clopidogrel and acetylsalicylic acid in bypass surgery for peripheral arterial disease (CASPAR) trial. J Vasc Surg. 2010;52(4):825-33. 833 e1. 2. [pmid: 20678878].
64 Tepe G, Bantleon R, Brechtel K, et al. Management of peripheral arterial interventions with mono or dual antiplatelet therapy-the MIRROR study: a randomised and double-blinded clinical trial. Eur Radiol. 2012;22(9):1998-2006. [pmid: 22569995].
65 Bhatt DL, Flather MD, Hacke W, et al. Patients with prior myocardial infarction, stroke, or symptomatic peripheral arterial disease in the CHARISMA trial. J Am Coll Cardiol. 2007;49(19):1982-8. [pmid: 17498584].
66 Crowther RG, Spinks WL, Leicht AS, et al. Effects of a long-term exercise program on lower limb mobility, physiological responses, walking performance, and physical activity levels in patients with peripheral arterial disease. J Vasc Surg. 2008;47(2):303-9. [pmid: 18241753].
67 Drozdz W, Panek J, Lejman W. Red cell deformability in patients with chronic atheromatous ischemia of the legs. Med Sci Monit. 2001;7(5):933-9. [pmid: 11535938].
68 Gardner AW, Katzel LI, Sorkin JD, et al. Effects of long-term exercise rehabilitation on claudication distances in patients with peripheral arterial disease: a randomized controlled trial. J Cardiopulm Rehabil. 2002;22(3):192-8. [pmid: 12042688].
69 Gardner AW, Parker DE, Montgomery PS, et al. Efficacy of quantified home-based exercise and supervised exercise in patients with intermittent claudication: a randomized controlled trial. Circulation. 2011;123(5):491-8. [pmid: 21262997].
70 Gelin J, Jivegard L, Taft C, et al. Treatment efficacy of intermittent claudication by surgical intervention, supervised physical exercise training compared to no treatment in unselected randomised patients I: one year results of functional and physiological improvements. Eur J Vasc Endovasc Surg. 2001;22(2):107-13. [pmid: 11472042].
71 Gibellini R, Fanello M, Bardile AF, et al. Exercise training in intermittent claudication. Int Angiol. 2000;19(1):8-13. [pmid: 10853679].
72 Giugliano G, Di Serafino L, Perrino C, et al. Effects of successful percutaneous lower extremity revascularization on cardiovascular outcome in patients with peripheral arterial disease. International Journal of Cardiology. 2012.
73 Hobbs SD, Marshall T, Fegan C, et al. The effect of supervised exercise and cilostazol on coagulation and fibrinolysis in intermittent claudication: a randomized controlled trial. J Vasc Surg. 2007;45(1):65-70. discussion 70. [pmid: 17210383].
74 Hobbs SD, Marshall T, Fegan C, et al. The constitutive procoagulant and hypofibrinolytic state in patients with intermittent claudication due to infrainguinal disease significantly improves with percutaneous transluminal balloon angioplasty. J Vasc Surg. 2006;43(1):40-6. [pmid: 16414385].
75 Lee HL, Mehta T, Ray B, et al. A non-randomised controlled trial of the clinical and cost effectiveness of a Supervised Exercise Programme for claudication. Eur J Vasc Endovasc Surg. 2007;33(2):202-7. [pmid: 17142065].
76 Mori E, Komori K, Kume M, et al. Comparison of the long-term results between surgical and conservative treatment in patients with intermittent claudication. Surgery. 2002;131(1 Suppl):S269-74. [pmid: 11821823].
77 Murphy TP, Cutlip DE, Regensteiner JG, et al. Supervised exercise versus primary stenting for claudication resulting from aortoiliac peripheral artery disease: six-month outcomes from the claudication: exercise versus endoluminal revascularization (CLEVER) study. Circulation. 2012;125(1):130-9. [pmid: 22090168].
78 Sugimoto I, Ohta T, Ishibashi H, et al. Conservative treatment for patients with intermittent claudication. Int Angiol. 2010;29(2 Suppl):55-60. [pmid: 20357750].
79 Tsai JC, Chan P, Wang CH, et al. The effects of exercise training on walking function and perception of health status in elderly patients with peripheral arterial occlusive disease. J Intern Med. 2002;252(5):448-55. [pmid: 12528763].
80 Greenhalgh RM, Belch JJ, Brown LC, et al. The adjuvant benefit of angioplasty in patients with mild to moderate intermittent claudication (MIMIC) managed by supervised exercise, smoking cessation advice and best medical therapy: results from two randomised trials for stenotic femoropopliteal and aortoiliac arterial disease. Eur J Vasc Endovasc Surg. 2008;36(6):680-8. [pmid: 19022184].
81 Kruidenier LM, Nicolai SP, Rouwet EV, et al. Additional supervised exercise therapy after a percutaneous vascular intervention for peripheral arterial disease: a randomized clinical trial. J Vasc Interv Radiol. 2011;22(7):961-8. [pmid: 21571547].
82 Mazari FA, Khan JA, Carradice D, et al. Randomized clinical trial of percutaneous transluminal angioplasty, supervised exercise and combined treatment for intermittent claudication due to femoropopliteal arterial disease. Br J Surg. 2012;99(1):39-48. [pmid: 22021102].
83 Nordanstig J, Gelin J, Hensater M, et al. Walking performance and health-related quality of life after surgical or endovascular invasive versus non-invasive treatment for intermittent claudication--a prospective randomised trial. Eur J Vasc Endovasc Surg. 2011;42(2):220-7. [pmid: 21397530].
84 Perkins JM, Collin J, Creasy TS, et al. Exercise training versus angioplasty for stable claudication. Long and medium term results of a prospective, randomised trial. Eur J Vasc Endovasc Surg. 1996;11(4):409-13. [pmid: 8846172].
85 Belcaro G, Nicolaides AN, Griffin M, et al. Intermittent claudication in diabetics: treatment with exercise and pentoxifylline--a 6-month, controlled, randomized trial. Angiology. Suppl 1. 2002;53:S39-43. [pmid: 11865835].
86 Dawson DL, Cutler BS, Meissner MH, et al. Cilostazol has beneficial effects in treatment of intermittent claudication: results from a multicenter, randomized, prospective, double-blind trial. Circulation. 1998;98(7):678-86. [pmid: 9715861].
87 De Sanctis MT, Cesarone MR, Belcaro G, et al. Treatment of intermittent claudication with pentoxifylline: a 12-month, randomized trial--walking distance and microcirculation. Angiology. Suppl 1. 2002;53:S7-12. [pmid: 11865838].
88 Hiatt WR, Money SR, Brass EP. Long-term safety of cilostazol in patients with peripheral artery disease: the CASTLE study (Cilostazol: A Study in Long-term Effects). J Vasc Surg. 2008;47(2):330-336. [pmid: 18155871].
89 Money SR, Herd JA, Isaacsohn JL, et al. Effect of cilostazol on walking distances in patients with intermittent claudication caused by peripheral vascular disease. J Vasc Surg. 1998;27(2):267-74. discussion 274-5. [pmid: 9510281].
90 Strandness DE Jr., Dalman RL, Panian S, et al. Effect of cilostazol in patients with intermittent claudication: a randomized, double-blind, placebo-controlled study. Vasc Endovascular Surg. 2002;36(2):83-91. [pmid: 11951094].
91 Feinglass J, McCarthy WJ, Slavensky R, et al. Functional status and walking ability after lower extremity bypass grafting or angioplasty for intermittent claudication: results from a prospective outcomes study. J Vasc Surg. 2000;31(1 Pt 1):93-103. [pmid: 10642712].
92 Koivunen K, Lukkarinen H. One-year prospective health-related quality-of-life outcomes in patients treated with conservative method, endovascular treatment or open surgery for symptomatic lower limb atherosclerotic disease. Eur J Cardiovasc Nurs. 2008;7(3):247-56. [pmid: 18221916].
93 Nylaende M, Abdelnoor M, Stranden E, et al. The Oslo balloon angioplasty versus conservative treatment study (OBACT)—The 2-years results of a single centre, prospective, randomised study in patients with intermittent claudication. Eur J Vasc Endovasc Surg. 2007;33(1):3-12. [pmid: 17055756].
94 Pell JP, Lee AJ. Impact of angioplasty and arterial reconstructive surgery on the quality of life of claudicants. The Scottish Vascular Audit Group. Scott Med J. 1997;42(2):47-8. [pmid: 9507581].
95 Whyman MR, Fowkes FG, Kerracher EM, et al. Is intermittent claudication improved by percutaneous transluminal angioplasty? A randomized controlled trial. J Vasc Surg. 1997;26(4):551-7. [pmid: 9357454].
96 Treat-Jacobson D, Bronas UG, Leon AS. Efficacy of arm-ergometry versus treadmill exercise training to improve walking distance in patients with claudication. Vasc Med. 2009;14(3):203-13. [pmid: 19651669].
97 Stone WM, Demaerschalk BM, Fowl RJ, et al. Type 3 phosphodiesterase inhibitors may be protective against cerebrovascular events in patients with claudication. J Stroke Cerebrovasc Dis. 2008;17(3):129-33. [pmid: 18436153].
98 De Sanctis MT, Cesarone MR, Belcaro G, et al. Treatment of long-distance intermittent claudication with pentoxifylline: a 12-month, randomized trial. Angiology. Suppl 1. 2002;53:S13-7. [pmid: 11865829].
99 Varty K, Nydahl S, Butterworth P, et al. Changes in the management of critical limb ischaemia. Br J Surg. 1996;83(7):953-6. [pmid: 8813785].
100 Ah Chong AK, Tan CB, Wong MW, et al. Bypass surgery or percutaneous transluminal angioplasty to treat critical lower limb ischaemia due to infrainguinal arterial occlusive disease?. Hong Kong Med J. 2009;15(4):249-54. [pmid: 19652230].
101 Dorigo W, Pulli R, Marek J, et al. A comparison between open and endovascular repair in the treatment of critical limb ischemia. Ital J Vasc Endovasc Surg. 2009;16(1):17-22.
102 Hynes N, Akhtar Y, Manning B, et al. Subintimal angioplasty as a primary modality in the management of critical limb ischemia: comparison to bypass grafting for aortoiliac and femoropopliteal occlusive disease. J Endovasc Ther. 2004;11(4):460-71. [pmid: 15298498].
103 Jerabek J, Dvorak M, Vojtisek B. Results of therapy of lower extremity ischemic disease by angiosurgery and radiointervention (PTA) methods. Bratisl Lek Listy. 2003;104(10):314-6. [pmid: 15055731].
104 Khan MU, Lall P, Harris LM, et al. Predictors of limb loss despite a patent endovascular-treated arterial segment. J Vasc Surg. 2009;49(6):1440-5. discussion 1445-6. [pmid: 19497503].
105 Korhonen M, Biancari F, Soderstrom M, et al. Femoropopliteal balloon angioplasty vs. bypass surgery for CLI: a propensity score analysis. Eur J Vasc Endovasc Surg. 2011;41(3):378-84. [pmid: 21195637].
106 Kudo T, Chandra FA, Kwun WH, et al. Changing pattern of surgical revascularization for critical limb ischemia over 12 years: endovascular vs. open bypass surgery. J Vasc Surg. 2006;44(2):304-13. [pmid: 16890859].
107 Laurila J, Brommels M, Standertskjold-Nordenstam CG, et al. Cost-effectiveness of Percutaneous Transluminal Angioplasty (PTA) Versus Vascular Surgery in Limb-threatening Ischaemia. Int J Angiol. 2000;9(4):214-219. [pmid: 11062310].
108 Loor G, Skelly CL, Wahlgren CM, et al. Is atherectomy the best first-line therapy for limb salvage in patients with critical limb ischemia?. Vasc Endovascular Surg. 2009;43(6):542-50. [pmid: 19640919].
109 Sultan S, Hynes N. Five-year Irish trial of CLI patients with TASC II type C/D lesions undergoing subintimal angioplasty or bypass surgery based on plaque echolucency. J Endovasc Ther. 2009;16(3):270-83. [pmid: 19642779].
110 Soderstrom MI, Arvela EM, Korhonen M, et al. Infrapopliteal percutaneous transluminal angioplasty versus bypass surgery as first-line strategies in critical leg ischemia: a propensity score analysis. Ann Surg. 2010;252(5):765-73. [pmid: 21037432].
111 Taylor SM, Kalbaugh CA, Blackhurst DW, et al. Determinants of functional outcome after revascularization for critical limb ischemia: an analysis of 1000 consecutive vascular interventions. J Vasc Surg. 2006;44(4):747-55. discussion 755-6. [pmid: 16926083].
112 Taylor SM, Kalbaugh CA, Blackhurst DW, et al. Postoperative outcomes according to preoperative medical and functional status after infrainguinal revascularization for critical limb ischemia in patients 80 years and older. Am Surg. 2005;71(8):640-5. discussion 645-6. [pmid: 16217945].
113 Taylor SM, York JW, Cull DL, et al. Clinical success using patient-oriented outcome measures after lower extremity bypass and endovascular intervention for ischemic tissue loss. J Vasc Surg. 2009;50(3):534-41. discussion 541. [pmid: 19592193].
114 Varela C, Acin F, De Haro J, et al. Influence of surgical or endovascular distal revascularization of the lower limbs on ischemic ulcer healing. J Cardiovasc Surg (Torino). 2011;52(3):381-9. [pmid: 21577193].
115 Venermo M, Biancari F, Arvela E, et al. The role of chronic kidney disease as a predictor of outcome after revascularisation of the ulcerated diabetic foot. Diabetologia. 2011. [pmid: 21845468].
116 Wolfle KD, Bruijnen H, Reeps C, et al. Tibioperoneal arterial lesions and critical foot ischaemia: successful management by the use of short vein grafts and percutaneous transluminal angioplasty. Vasa. 2000;29(3):207-14. [pmid: 11037720].
117 Zdanowski Z, Troeng T, Norgren L. Outcome and influence of age after infrainguinal revascularisation in critical limb ischaemia. The Swedish Vascular Registry. Eur J Vasc Endovasc Surg. 1998;16(2):137-41. [pmid: 9728433].
118 Faglia E, Clerici G, Losa S, et al. Limb revascularization feasibility in diabetic patients with critical limb ischemia: results from a cohort of 344 consecutive unselected diabetic patients evaluated in 2009. Diabetes Res Clin Pract. 2012;95(3):364-71. [pmid: 22104261].
119 Dosluoglu HH, Lall P, Harris LM, et al. Long-term limb salvage and survival after endovascular and open revascularization for critical limb ischemia after adoption of endovascular-first approach by vascular surgeons. Journal of Vascular Surgery. 2012.
120 Johnson BF, Singh S, Evans L, et al. A prospective study of the effect of limb-threatening ischaemia and its surgical treatment on the quality of life. Eur J Vasc Endovasc Surg. 1997;13(3):306-14. [pmid: 9129605].
121 Hoshino J, Fujimoto Y, Naruse Y, et al. Characteristics of revascularization treatment for arteriosclerosis obliterans in patients with and without hemodialysis. Circ J. 2010;74(11):2426-33. [pmid: 20938099].
122 Janne d'Othee B, Morris MF, Powell RJ, et al. Cost determinants of percutaneous and surgical interventions for treatment of intermittent claudication from the perspective of the hospital. Cardiovasc Intervent Radiol. 2008;31(1):56-65. [pmid: 17973158].
123 Lepantalo M, Laurila K, Roth WD, et al. PTFE bypass or thrupass for superficial femoral artery occlusion? A randomised controlled trial. Eur J Vasc Endovasc Surg. 2009;37(5):578-84. [pmid: 19231250].
124 McQuade K, Gable D, Hohman S, et al. Randomized comparison of ePTFE/nitinol self-expanding stent graft vs prosthetic femoral-popliteal bypass in the treatment of superficial femoral artery occlusive disease. J Vasc Surg. 2009;49(1):109-15. 116 e1. 9. discussion 116. [pmid: 19028055].
125 Rossi E, Citterio F, Castagneto M, et al. Safety of endovascular treatment in high-cardiac-risk patients with limb-threatening ischemia. Angiology. 1998;49(6):435-40. [pmid: 9631888].
126 Sachs T, Pomposelli F, Hamdan A, et al. Trends in the national outcomes and costs for claudication and limb threatening ischemia: Angioplasty vs bypass graft. J Vasc Surg. 2011;54(4):1021-1031 e1. [pmid: 21880457].
127 Stoner MC, Defreitas DJ, Manwaring MM, et al. Cost per day of patency: understanding the impact of patency and reintervention in a sustainable model of healthcare. J Vasc Surg. 2008;48(6):1489-96. [pmid: 18829227].
128 Timaran CH, Prault TL, Stevens SL, et al. Iliac artery stenting versus surgical reconstruction for TASC (TransAtlantic Inter-Society Consensus) type B and type C iliac lesions. J Vasc Surg. 2003;38(2):272-8. [pmid: 12891108].
129 Timaran CH, Ohki T, Gargiulo NJ 3rd, et al. Iliac artery stenting in patients with poor distal runoff: Influence of concomitant infrainguinal arterial reconstruction. J Vasc Surg. 2003;38(3):479-84. discussion 484-5. [pmid: 12947261].
130 Whatling PJ, Gibson M, Torrie EP, et al. Iliac occlusions: stenting or crossover grafting? An examination of patency and cost. Eur J Vasc Endovasc Surg. 2000;20(1):36-40. [pmid: 10906295].
131 Kashyap VS, Pavkov ML, Bena JF, et al. The management of severe aortoiliac occlusive disease: endovascular therapy rivals open reconstruction. J Vasc Surg. 2008;48(6):1451-7. 1457 e1. 3. [pmid: 18804943].
132 Kamiya C, Sakamoto S, Tamori Y, et al. Long-term outcome after percutaneous peripheral intervention vs medical treatment for patients with superficial femoral artery occlusive disease. Circ J. 2008;72(5):734-9. [pmid: 18441452].
133 Lawall H, Gorriahn H, Amendt K, et al. Long-term outcomes after medical and interventional therapy of critical limb ischemia. Eur J Intern Med. 2009;20(6):616-21. [pmid: 19782924].
134 Adams J, Ogola G, Stafford P, et al. High-intensity interval training for intermittent claudication in a vascular rehabilitation program. J Vasc Nurs. 2006;24(2):46-9. [pmid: 16737929].
135 Kedora J, Hohmann S, Garrett W, et al. Randomized comparison of percutaneous Viabahn stent grafts vs prosthetic femoral-popliteal bypass in the treatment of superficial femoral arterial occlusive disease. J Vasc Surg. 2007;45(1):10-6. discussion 16. [pmid: 17126520].
136 McQuade K, Gable D, Pearl G, et al. Four-year randomized prospective comparison of percutaneous ePTFE/nitinol self-expanding stent graft versus prosthetic femoral-popliteal bypass in the treatment of superficial femoral artery occlusive disease. J Vasc Surg. 2010;52(3):584-90. discussion 590-1. 591 e1. 591 e7. [pmid: 20598480].
137 Wong Peng F, Chong Lee Y, Mikhailidis Dimitris P, et al. Antiplatelet agents for intermittent claudication. Cochrane Database of Systematic Reviews. 2011;(11).
138 Frans FA, Bipat S, Reekers JA, et al. Systematic review of exercise training or percutaneous transluminal angioplasty for intermittent claudication. Br J Surg. 2011. [pmid: 21928409].
139 Leng GC, Fowler B, Ernst E. Exercise for intermittent claudication. Cochrane Database Syst Rev. 2000;(2):CD000990. [pmid: 10796572].
140 Watson L, Ellis B, Leng GC. Exercise for intermittent claudication. Cochrane Database Syst Rev. 2008;(4):CD000990. [pmid: 18843614].
141 National Institute for Health and Clinical Excellence. Lower limb peripheral arterial disease: diagnosis and management. NICE Clinical Guideline [draft]. March. 2012. www.nice.org.uk/guidance/index.jsp?action=folder&o=58406. May 22, 2012.
142 Robless P, Mikhailidis DP, Stansby GP. Cilostazol for peripheral arterial disease. Cochrane Database Syst Rev. 2008;(1):CD003748. [pmid: 18254032].
143 Girolami B, Bernardi E, Prins MH, et al. Treatment of intermittent claudication with physical training, smoking cessation, pentoxifylline, or nafronyl: a meta-analysis. Arch Intern Med. 1999;159(4):337-45. [pmid: 10030306].
144 Leng GC, Davis M, Baker D. Bypass surgery for chronic lower limb ischaemia. Cochrane Database Syst Rev. 2000;(3):CD002000. [pmid: 10908520].
145 Bradbury AW, Adam DJ, Bell J, et al. Bypass versus Angioplasty in Severe Ischaemia of the Leg (BASIL) trial: An intention-to-treat analysis of amputation-free and overall survival in patients randomized to a bypass surgery-first or a balloon angioplasty-first revascularization strategy. J Vasc Surg. 2010;51(5 Suppl):5S-17S. [pmid: 20435258].
146 Agency for Healthcare Research and Quality. Horizon Scan of Invasive Interventions for Lower Extremity Peripheral Artery Disease and Systematic Review of Studies Comparing Stent Placement to Other Interventions. Technology Assessment. October. 2008. www.cms.gov/Medicare/Coverage/DeterminationProcess/downloads//id63TA.pdf. May 22, 2012.
147 Robinson KA, Saldanha IJ, Mckoy NA. Frameworks for Determining Research Gaps During Systematic Reviews. Methods Future Research Needs Report No. 2. (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. 290-2007-10061-I.) AHRQ Publication No. 11-EHC043-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2011. www.effectivehealthcare.ahrq.gov/reports/final.cfm. May 22, 2012.