# Methods

The methods for this comparative effectiveness review follow those suggested in the AHRQ “Methods Guide for Effectiveness and Comparative Effectiveness Reviews” (www.effectivehealthcare.ahrq.gov/methodsguide.cfm; hereafter referred to as the Methods Guide).45 The main sections in this chapter reflect the elements of the protocol established for the systematic review; certain methods map to the PRISMA checklist.46 All methods and analyses were determined a priori. Figure 2 depicts the steps undertaken for this systematic review.

Figure 2 Steps of a systematic review

This figure depicts the steps undertaken for this systematic review: (1) Topic refinement and review, (2) literature search, (3) study selection, (4) data extraction, (5) quality and applicability assessment, (6) data synthesis, (7) grading the strength of the body of evidence, (8) peer and public review, and (9) final report.

## Topic Refinement and Review Protocol

During the topic refinement stage, we solicited input from KIs representing clinicians (cardiology, radiology, vascular surgery, general medicine, and nursing), patients, scientific experts, and Federal agencies, to help define the KQs. The KQs were then posted for public comment for 30 days, and the comments received were considered in the development of the research protocol. We next convened a TEP comprising clinical, content, and methodological experts to provide input in defining populations, interventions, comparisons, or outcomes as well as identifying particular studies or databases to search. The KIs and members of the TEP were required to disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Any potential conflicts of interest were balanced or mitigated. Of the 10 TEP members, four held positions on scientific advisory boards representing 14 entities, of which two members overlapped on two entities; thus there was not majority interest in any particular company or institute. Neither KIs nor members of the TEP did analysis of any kind and did not contribute to the writing of the report. Members of the TEP were invited to provide feedback on an initial draft of the review protocol, which was then refined based on their input, reviewed by AHRQ, and posted for public access at the AHRQ Effective Health Care Web site.47

## Literature Search Strategy

### Sources Searched

Our search strategy used the National Library of Medicine's medical subject headings (MeSH) keyword nomenclature developed for MEDLINE^®^ and adapted for use in other databases. In consultation with our research librarians, we searched PubMed^®^, Embase^®^, and the Cochrane Database of Systematic Reviews from January 1, 1995, to August 13, 2012. During peer and public review of this draft report, we updated the database searches and included any eligible studies identified either through that search or through suggestions from peer and public reviewers. Our search strategy for PubMed is included in Appendix A; this strategy was adapted as necessary for use in the other databases. We date-limited our search to articles published since January 1995, corresponding with the time period when contemporary studies on antiplatelet therapy, exercise training, endovascular interventions and surgical revascularization were published. We supplemented the electronic searches with a manual search of references from 132 systematic review articles, of which 10 articles were included. The reference list for identified pivotal articles was hand-searched and cross-referenced against our library, and 19 additional manuscripts were retrieved. All citations were imported into an electronic database (EndNote^®^ X4; Thomson Reuters, Philadelphia, PA).

We also searched the gray literature of study registries and conference abstracts for relevant articles from completed studies and identified nine peer-reviewed articles for full-text screening. Gray literature databases included ClinicalTrials.gov; metaRegister of Controlled Trials; WHO International Clinical Trials Registry Platform Search Portal; and ProQuest COS Conference Papers Index. Scientific information packets were requested from the manufacturers of medications and devices and seven packets were received. These were reviewed for relevant articles from completed studies not previously identified in the literature searches, and no new publications were found (all suggested citations had been previously identified).

### Inclusion and Exclusion Criteria

The PICOTS criteria used to screen articles for inclusion/exclusion at both the title-and-abstract and full-text screening stages are detailed in Table 3. Note that because study data in patients with PAD are limited—and because the indications for statin and angiotensin-converting enzyme inhibitor (ACE-I) therapy are based on baseline lipid levels, diabetic status, and blood pressure (all risk factors for PAD)—we did not include studies of these drugs in this review. These drugs are often covered and evaluated for those specific primary conditions. The management of risk factors (i.e., tobacco use, diabetes, LDL levels, and hypertension) is considered standard therapy for all patients with or without PAD regardless of PAD classification and was therefore considered concurrent therapy with the medical and revascularization strategies examined in this review.

Table 3 Inclusion and exclusion criteria

Study Characteristic | Inclusion Criteria | Exclusion Criteria
Population | Adult patients (≥18 years of age) with lower extremity PAD (e.g., ABI <0.9) who are asymptomatic or symptomatic (atypical leg symptoms, IC, or CLI) | - Patients with PAD, but results are not reported separately for the subgroup with lower extremity PAD; - All patients are <18 years of age, or some patients are <18 years of age, but results are not broken down by age
Interventions and comparators | - KQ 1: Two or more antiplatelet agents (aspirin or clopidogrel); - KQ 2:; ○ Exercise training vs. medications (cilostazol, pentoxifylline); ○ Exercise training vs. endovascular intervention (percutaneous transluminal arterial angioplasty, atherectomy, stenting); ○ Exercise training vs. surgical revascularization (endarterectomy, bypass surgery); ○ Medications vs. endovascular intervention; ○ Medications vs. surgical revascularization; ○ Usual care vs. another treatment modality (exercise training, medications, endovascular intervention, or surgical revascularization); - KQ 3:; ○ Endovascular intervention (percutaneous transluminal arterial angioplasty, atherectomy, stenting) vs. surgical revascularization (endarterectomy, bypass surgery); ○ Usual care vs. endovascular intervention; ○ Usual care vs. surgical revascularization | - Interventions not listed in KQs 1–3 (e.g., studies of tobacco cessation, statins, and were excluded since treatment of cardiovascular risk factors is considered standard therapy across the treatment strategies assessed in this report); - KQ 1: No active comparator (but placebo-controlled trials and studies comparing one antiplatelet agent with another antiplatelet agent are included); also excluded:; ○ Studies of ticlopidine (no longer prescribed due to hematologic side effects); ○ Studies comparing anticoagulants (warfarin, low molecular weight heparin) with antiplatelet agents to prevent postrevascularization thrombosis; - KQ 2 and KQ 3: No active comparator (but studies comparing usual care or placebo with another treatment are included), or comparisons of two treatments of the same type (i.e., one type of exercise vs. another type of exercise; endovascular approach vs. another endovascular approach; surgical approach vs. another surgical approach)
Outcomes | KQs 1–3:; - Functional capacity (e.g., PWT, MWD or PFWD, COT, and initial or ACD); - Quality of life (e.g., Short-Form 36, EuroQOL-5D, Walking Impairment Questionnaire, Peripheral Artery Questionnaire); - Vessel patency (primary, primary assisted, or secondary); - Repeat revascularization; - Amputation; - Wound healing; - Analog pain scale score; - Cardiovascular events (e.g., all-cause mortality, MI, stroke, cardiovascular death) | No primary or secondary outcomes of interest are reported
Outcomes (safety) | KQs 1–3: Intervention-related safety and adverse effects including adverse drug reactions, bleeding, contrast nephropathy, radiation, infection, exercise-related harms, and periprocedural complications causing acute limb ischemia | None
Timing | Short term (30 days), intermediate term (31 days to 1 year), and long term (>1 year) | Treatment or followup of <30 days
Setting | Inpatient and outpatient | None
Study design | - Randomized controlled trial, prospective or retrospective observational cohort study; - Relevant systematic review or meta-analysis (used for background only); - Original data (or related methodology paper of an included article) for interventions listed in KQs 1–3; - All sample sizes | Not a clinical study (e.g., editorial, non–systematic review, letter to the editor, case series)
Publications | - English-language only; - Peer-reviewed article; - Published January 1, 1995, to present | Given the high volume of literature available in English-language publications (including the majority of known important studies), non-English articles were excluded

Abbreviations: ABI=ankle-brachial index; ACD=absolute claudication distance; COT=claudication onset time; KQ=Key Question; PAD=peripheral artery disease; PWT=peak walking time; PFWD=pain-free walking distance.

### Study Selection

Using the prespecified inclusion and exclusion criteria, titles and abstracts were examined independently by two reviewers for potential relevance to the KQs. Articles included by any reviewer underwent full-text screening. At the full-text screening stage, two independent reviewers read each article to determine if it met eligibility criteria. At the full-text review stage, paired researchers independently reviewed the articles and indicated a decision to “include” or “exclude” the article for data abstraction. When the paired reviewers arrived at different decisions about whether to include or exclude an article, we reconciled the difference through a third-party arbitrator. Articles meeting our eligibility criteria were included for data abstraction. Relevant systematic review articles, meta-analyses, and methods articles were flagged for hand-searching and cross-referencing against the library of citations identified through electronic database searching.

### Data Extraction

The investigative team created data abstraction forms and evidence table templates for abstracting data for the KQs. Based on clinical and methodological expertise, two investigators were assigned to the research questions to abstract data from the eligible articles. One investigator abstracted the data, and the second overread the article and the accompanying abstraction to check for accuracy and completeness. Disagreements were resolved by consensus or by obtaining a third reviewer's opinion if consensus was not reached between the first two investigators.

To aid in both reproducibility and standardization of data collection, investigators received data abstraction instructions directly on each form created specifically for this project with the DistillerSR data synthesis software program (Evidence Partners Inc., Manotick, ON, Canada). Data reported only in graphs were estimated quantitatively using Engauge Digitizer version 4.1 software (www.digitizer.sourceforge.net).

We designed the data abstraction forms for this project to collect data required to evaluate the specified eligibility criteria for inclusion in this review, as well as demographic and other data needed for determining outcomes (intermediate outcomes, health outcomes, and safety outcomes). Variables collected include:

- Demographic factors such as age, sex, and race
- Vascular disease risk factors such as diabetes, tobacco use, chronic kidney disease, hyperlipidemia, or other comorbid disease
- Intervention-specific factors such as dose of aspirin monotherapy, use of DAPT, type of exercise training, duration of exercise training, type of endovascular revascularization procedure (angioplasty, stenting, atherectomy), or type of surgical revascularization procedure (endarterectomy, surgical bypass)
- Anatomy-specific factors such as location of stenosis, pattern of stenosis, burden of disease, degree of calcification, or number of below-knee vessel runoff
- Patient-specific factors such as asymptomatic state, presence of atypical leg symptoms, IC or CLI
- Hospital characteristics such as hospital patient volume, setting, guideline-based treatment protocols

Safety outcomes were framed to help identify adverse events, including adverse drug reactions, contrast nephropathy, radiation exposure, infection, bleeding, exercise-related harms, and periprocedural complications causing acute limb ischemia

Data necessary for assessing quality and applicability, as described in the Methods Guide,45 were also abstracted. Before they were used, abstraction form templates were pilot tested with a sample of included articles to ensure that all relevant data elements were captured and that there was consistency and reproducibility between abstractors. During the early phase of abstraction, forms were revised when relevant data elements were found in the published literature and needed to be captured in the database before full abstraction of all included articles. Appendix B lists the data elements used in the data abstraction forms.

## Quality Assessment of Individual Studies

We evaluated the quality of individual studies using the approach described in the Methods Guide.45 To assess quality, we used the strategy to (1) classify the study design, (2) apply predefined criteria for quality and critical appraisal, and (3) arrive at a summary judgment of the study's quality. To evaluate methodological quality, we applied criteria for each study type derived from the core elements described in the Methods Guide. For RCTs, criteria included adequacy of randomization and allocation concealment; the comparability of groups at baseline; blinding; the completeness of followup and differential loss to followup; whether incomplete data were addressed appropriately; the validity of outcome measures; and conflict of interest.

For observational studies, we assessed the following study-specific issues that may affect the internal validity of our systematic review: potential for selection bias (i.e., degree of similarity between intervention and control patients); performance bias (i.e., differences in care provided to intervention and control patients not related to the study intervention); attribution and detection bias (i.e., whether outcomes were differentially detected between intervention and control groups); and magnitude of reported intervention effects (see the section on “Selecting Observational Studies for Comparing Medical Interventions” in the Methods Guide).

To indicate the summary judgment of the quality of the individual studies, we used the summary ratings of good, fair, or poor based on their adherence to well-accepted standard methodologies and adequate reporting (Table 4).

Table 4 Definitions of overall quality ratings

Quality Rating | Description
Good | A study with the least bias; results are considered valid. A good study has a clear description of the population, setting, interventions, and comparison groups; uses a valid approach to allocate patients to alternative treatments; has a low dropout rate; and uses appropriate means to prevent bias, measure outcomes, and analyze and report results.
Fair | A study that is susceptible to some bias but probably not enough to invalidate the results. The study may be missing information, making it difficult to assess limitations and potential problems. As the fair-quality category is broad, studies with this rating vary in their strengths and weaknesses. The results of some fair-quality studies are possibly valid, while others are probably valid.
Poor | A study with significant bias that may invalidate the results. These studies have serious errors in design, analysis, or reporting; have large amounts of missing information; or have discrepancies in reporting. The results of a poor-quality study are at least as likely to reflect flaws in the study design as to indicate true differences between the compared interventions.

Included meta-analyses were appraised according to criteria adapted from the PRISMA Statement.46 Grading was outcome specific; thus, a given study may have been graded of different quality for two individual outcomes reported within that study. Study design also was considered when grading quality. RCTs were graded as good, fair, or poor. Observational studies were graded separately, also as good (low risk of bias), fair (moderate risk of bias), or poor (high risk of bias). Appendix C summarizes our assessment of the quality and applicability for each included study.

## Data Synthesis

We summarized the primary literature by abstracting relevant continuous (e.g., age, event rates) and categorical (e.g., race, presence of coronary disease risk factors) data. Continuous variable outcomes were summarized using what was reported by the authors. This included means, medians, standard deviations, interquartile ranges, ranges, and associated p-values. Dichotomous variables were summarized by proportions and associated p-values. We then determined the feasibility of completing a quantitative synthesis (i.e., meta-analysis). Feasibility depended on the volume of relevant literature, conceptual homogeneity of the studies, and completeness of the reporting of results. We considered meta-analysis for comparisons where at least three studies reported the same outcome at similar followup intervals.

Meta-analyses were based on the nature of the outcome variable, but random-effects models were used for all outcomes because of the heterogeneity of the studies. Continuous outcome measures comparing two treatments that used a similar scale were combined without transformation using a random-effects model as implemented in Comprehensive Meta-Analysis Version 2 (Biostat; Englewood, NJ). Continuous outcome measures comparing two treatments made on different scales (such as quality of life measures) were combined using a random-effects model on the effect sizes as implemented in Comprehensive Meta-Analysis. Dichotomous outcome measures comparing two treatments were combined and odds ratios were computed using a random-effects model as implemented ion.

For KQ 2, because several of the studies reported results from multiple treatment arms and used different measures for a similar outcome, we constructed an effect size for each relevant arm of each study and employed the methods of indirect comparative meta-analysis. We used a random-effects model that was a generalization of the standard random-effects model used in the meta-analysis of effect sizes. We assumed that each effect size for each arm, ES_ij_, could be described by the following model:

E S_i j_ = α_i_ + ∑_j = 1_^5^ x_i j_ β_j_ ,

where i denotes the study and j denotes the specific treatment within a study. The αi represents the mean for placebo and assumed to be random and normal with variance (SEij2 + σ2). SEij is the standard error of the jth effect size from the ith study. σ2 is the extra variation from the random effects model. The xij are “1” if the jth treatment is present, and “0” otherwise. The βj (j=1, … , 6) are the treatment effects ratios to be estimated for each treatment.

The model was fitted using SAS PROC NLMIXED (SAS Institute Inc.; Cary, NC) with “subject” set to the particular study, i. Any studies without estimates of the treatment effects, or without estimates of the variation or exact p-values, were excluded. This type of analysis was used for the maximal walking, claudication onset, and quality of life measures.

Effect size interpretation is based on Cohen's d, whereby 0 equates to no effect, 0.2 equates to a small effect, 0.5 equates to a medium effect, 0.8 equates to a large effect, and effects larger than 1.0 equate to very large effects.48 The p-value is an indication of the significance of the effect, which is also reflected by the confidence interval around the summary estimate. Factors influencing the significance of the effect (or p-value) include the number of studies contributing to the estimate, the standard error of each individual study, and the heterogeneity of the individual study results.

Table 5 shows an example of effect size data for the Short Form-36 Item (SF-36) physical function score reported in Beebe et al., 1999^49^ (from Table 4 of the publication). This three-arm study reported results for the endpoint of percent change from baseline of the physical function score.

Table 5 Example effect size calculation^a^

Arm | Sample Size | Percent Change
Cilostazol, 100 mg | 106 | 7.1
Cilostazol, 50 mg | 108 | 8.0
Placebo | 102 | 2.0

a From Beebe et al.49

The authors reported a p-value of 0.02 for the three-way comparison. From this we used the inverse incomplete beta function to back-calculate the F-value, assuming 2 and 313 degrees of freedom. The corresponding F value is 3.961. Knowing the F value, we can calculate the mean square error. This value is 274.46. The square root of this value, 16.57, is the estimate of the pooled standard deviation. In order to calculate the effect size for cilostazol 100 mg versus placebo, we subtract 2.0 from 7.1 and divide by 16.57. This gives an effect size value of 0.31, which translates into a small effect of cilostazol when compared with placebo. The standard error of this value is the square root of the sum of the reciprocals of the samples sizes: √(1/106 + 1/102)=0.14.

For the mortality outcome in KQ 2, the challenge of combining evidence from studies with several different treatment arms goes beyond standard meta-analysis techniques. The solution to the problem requires that we define parameters that describe the possible interventions. We made the same assumption that is used in standard meta-analyses, that is, we assumed that the odds ratio (or any other effect measure) comparing two treatments remains constant across studies. Because there are several different treatments, we assumed that all of the odds ratios between the various treatments remained constant. Thus the model made the same general assumptions as the Mantel-Haenszel method, one of the standard methods for combining odds ratios.

Because our outcome measures are dichotomous, they can be fitted using multiple logistic regression analysis. Dummy variables (α_j_'s) are used for study differences and treatment variables (β_k_'s) are used for various treatment effects. As is often done in meta-analyses, we used a random effects analysis. The random effects model is the same as that used for the fixed effects analysis, except that the model includes a coefficient, θ, times an error term:

L n [ (p_i_ ( x ))/(1 − p_i_ ( x )) ] = ∑_j = 1_^m^ α_j_ x_i j_ + ∑_k = 1_^m^ β_k_ x_k j_ + θ ε_i_

where p_i_(x) is the probability of an event in the i^th^ arm, ɛ_i_ is a standard normal random variable. This model can be fitted using the EGRET software (Cytel Software Corporation; Cambridge, MA) that estimates both fixed and random effects parameters and automatically generates the dummy variables (α's) for each study (Logistic-Normal Regression Model option). Hasselblad50 described the application of this methodology to meta-regression problems. In order to minimize the impact that study populations and disease severity may have on clinical outcomes, we reviewed the PAD definition for study inclusion and the baseline population characteristics and found similar eligibility criteria and mean ABIs at study enrollment (within one standard deviation of each other). Therefore we did not perform statistical adjustment for the baseline severity of PAD. All studies were RCTs, most of which were good quality, and so randomization would have controlled for any selection and population bias in each treatment arm. Additionally, we performed a sensitivity analysis without one study51 since it was a combination of cilostazol with percutaneous transluminal angioplasty versus placebo with percutaneous transluminal angioplasty, and there was minimal impact on the summary estimate for the cilostazol studies.

Given the heterogeneity of study design and patient population in KQ 3, we grouped the studies by study design (observational or RCT) and by population (CLI or mixed IC-CLI population) to evaluate the summary estimates for each study design-population combination separately and its contribution to the overall summary estimate.

We tested for statistical heterogeneity between studies (Q and I^2^ statistics) while recognizing that the power to detect such heterogeneity may be limited. Potential heterogeneity between studies was reflected through the confidence intervals of the summary statistics obtained from a random-effects approach. We present summary estimates, standard errors, and confidence intervals in our data synthesis.

## Strength of the Body of Evidence

The strength of evidence (SOE) for each KQ was assessed using the approach described in the Methods Guide.52 The evidence was evaluated using the four required domains: risk of bias, consistency, directness, and precision (Table 6).

Table 6 SOE required domains

Domain | Rating | How Assessed
Risk of bias | Low Medium High | Assessed primarily through study design (randomized controlled trial versus observational study) and aggregate study quality
Consistency | Consistent Inconsistent Unknown/not applicable | Assessed primarily through whether effect sizes are generally on the same side of “no effect” and the overall range of effect sizes
Directness | Direct Indirect | Assessed by whether the evidence involves direct comparisons or indirect comparisons through use of surrogate outcomes or use of separate bodies of evidence
Precision | Precise Imprecise Unknown/not applicable | Based primarily on the size of the confidence intervals of effect estimates

Additionally, when appropriate, the studies were evaluated for dose-response association, the presence of confounders that would diminish an observed effect, strength of association (magnitude of effect), and publication bias. These domains were considered qualitatively, and a summary rating of high, moderate, or low SOE was assigned after discussion by two reviewers. In some cases, high, moderate, or low ratings were impossible or imprudent to make; for example, when no evidence was available or when evidence on the outcome was too weak, sparse, or inconsistent to permit any conclusion to be drawn. In these situations, a grade of insufficient was assigned. This four-level rating scale consists of the following definitions:

- High—High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
- Moderate—Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
- Low—Low confidence that the evidence reflects the true effect. Further research is likely to change the confidence in the estimate of effect and is likely to change the estimate.
- Insufficient—Evidence either is unavailable or does not permit estimation of an effect.

## Applicability

We assessed applicability across our KQs using the method described in the Methods Guide.45,53 In brief, the latter methods use the PICOTS format as a way to organize information relevant to applicability. We used these data to evaluate the applicability to clinical practice, paying special attention to study eligibility criteria, demographic features of the enrolled population (such as age, ethnicity, and sex) in comparison with the target population, version or characteristics of the intervention used in comparison with therapies currently in use (such as specific components of treatments considered to be “optimal medical therapy,” plus advancements in endovascular and surgical revascularization techniques that have changed over time), and clinical relevance and timing of the outcome measures. We used a checklist to guide our assessment and summarized issues of applicability qualitatively (Appendix B).

## Peer Review and Public Commentary

The peer review process is our principal external quality-monitoring device. Nominations for peer reviewers were solicited from several sources, including the TEP and interested Federal agencies. Experts in cardiology, radiology, vascular surgery, general medicine, and nursing, along with individuals representing stakeholder and user communities, were invited to provide external peer review of the draft report; AHRQ and an associate editor also provided comments. The draft report was posted on the AHRQ Web site for 4 weeks, from October 3 to November 7, 2012. We have addressed reviewer comments, revising the report as appropriate, and have documented our responses in a disposition of comments report available on the AHRQ Web site. A list of peer reviewers is given in the preface of this report.