# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Mike S. Conte, M.D.
  Codirector, Heart and Vascular Center
  University of California San Francisco Medical Center
  San Francisco, CA
- Mark Creager, M.D.
  Director, Vascular Center
  Brigham and Women's Hospital, Cardiovascular Division
  Boston, MA
- Mary McDermott, M.D.
  Professor of Medicine and Preventive Medicine
  Northwestern University Feinberg School of Medicine
  Chicago, IL
- David Moher
  Senior Scientist, Clinical Epidemiology
  Ottawa Hospital Research Institute
  Ottawa, Ontario, Canada
- Sanjay Misra, M.D.
  Associate Professor of Radiology
  Mayo Clinic
  Rochester, MN
- Jeffrey Olin, M.D.
  Professor of Medicine, Cardiology
  Mount Sinai School of Medicine
  New York, NY
- Diane Reid, M.D.
  Division of Heart and Vascular Diseases
  National Heart, Lung, and Blood Institute
  Bethesda, MD
- Diane Treat-Jacobsen, Ph.D., R.N.
  Associate Professor and Chair, Adult & Gerontological Health Cooperative
  University of Minnesota School of Nursing
  Minneapolis, MN
- David Vanness, Ph.D.
  Associate Professor of Population Health Sciences
  Affiliate, Center for Demography and Ecology
  University of Wisconsin School of Medicine and Public Health
  Madison, WI
- Christopher White, M.D.
  Director, John Ochsner Heart & Vascular Institute
  Ochsner Medical Center
  New Orleans, LA