# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Peter Alagona, M.D.
  Penn State Hershey Heart and Vascular Institute
  Hershey, PA
- Mike S. Conte, M.D.
  Codirector, Heart and Vascular Center
  University of California San Francisco Medical Center
  San Francisco, CA
- Mark Creager, M.D.
  Director, Vascular Center
  Brigham and Women's Hospital, Cardiovascular Division
  Boston, MA
- Mary McDermott, M.D.
  Professor of Medicine and Preventive Medicine
  Northwestern University Feinberg School of Medicine
  Chicago, IL
- Sanjay Misra, M.D.
  Associate Professor of Radiology
  Mayo Clinic
  Rochester, MN
- Erin O'Connell Peiffer
  Spokesperson
  WomenHeart
  Baltimore, MD
- Jeffrey Olin, M.D.
  Professor of Medicine, Cardiology
  Mount Sinai School of Medicine
  New York, NY
- Diane Reid, M.D.
  Division of Heart and Vascular Diseases
  National Heart, Lung, and Blood Institute
  Bethesda, MD
- Diane Treat-Jacobsen, Ph.D., R.N.
  Associate Professor and Chair, Adult & Gerontological Health Cooperative
  University of Minnesota School of Nursing
  Minneapolis, MN
- Christopher White, M.D.
  Director, John Ochsner Heart & Vascular Institute
  Ochsner Medical Center
  New Orleans, LA