# Acknowledgments

The authors thank Megan von Isenburg, M.S.L.S., for help with the literature search and retrieval.