# Discussion

## Key Findings and SOE

In this comparative effectiveness review, we identified the following studies:

- Eleven studies (10 RCTs, 1 observational), involving 15,150 patients, that assessed the effectiveness of aspirin, clopidogrel, or other antiplatelet agents on cardiovascular outcomes in the PAD population (KQ 1)
- Thirty-five studies (27 RCTs, 8 observational), involving 7475 patients with IC, that assessed the effectiveness of exercise training, medication, endovascular intervention, and/or surgical revascularization on functional outcomes, quality of life, and cardiovascular events (KQ 2)
- Thirty-seven studies (3 RCTs, 34 observational) that assessed the effectiveness of usual care, endovascular intervention, or surgical revascularization on vessel patency, amputation, mortality, and amputation-free survival (KQ 3). Of these, 23 studies (1 RCT, 22 observational) involved 12,779 patients with CLI and 12 studies (2 RCTs, 10 observational) involved 565,168 patients with IC or CLI.

### KQ 1 Comparative Effectiveness and Safety of Antiplatelet Therapy in Adults With PAD

Our review of antiplatelet agents shows that the comparative effectiveness for prevention of cardiovascular disease appears to vary by PAD severity and medication. In asymptomatic PAD patients with no previous cardiovascular disease, including asymptomatic PAD patients with diabetes, aspirin 100 mg daily did not reduce vascular events or mortality compared with placebo from two good quality RCTs. In PAD patients with IC, aspirin reduced the rates of fatal and nonfatal MI as well as other vascular events when compared to placebo in one fair quality RCT.

The comparative effectiveness of clopidogrel versus aspirin has been studied in one good-quality RCT (CAPRIE), which found clopidogrel more effective at reducing cardiovascular mortality, nonfatal MI, and composite vascular events. Clopidogrel and aspirin appeared to be equivalent for prevention of nonfatal stroke, but the confidence interval was wide, making this conclusion less certain.

DAPT with clopidogrel plus aspirin has been compared with aspirin monotherapy. In a predominately IC population, the CHARISMA RCT showed no difference between aspirin and dual therapy (clopidogrel plus aspirin) for outcomes of all-cause mortality, nonfatal stroke, cardiovascular mortality, or composite vascular events; however, it showed a statistically significant benefit favoring dual therapy compared with aspirin for reducing nonfatal MI. In a mixed IC and CLI population randomized to dual antiplatelet versus aspirin therapy after unilateral bypass graft, DAPT resulted in no difference in nonfatal stroke and composite vascular events. In patients with IC or CLI after endovascular procedure, the MIRROR study showed no difference between dual therapy and aspirin in cardiovascular events or mortality at 6 months but was insufficiently powered for those outcomes.

Four additional studies assessed other antiplatelet comparisons. One poor-quality retrospective study of 113 CLI patients after infrainguinal bypass comparing aspirin with no-aspirin therapy showed no differences in the rate of graft failure or vascular death between the groups. One good-quality RCT in 103 IC patients after PTA comparing DAPT with aspirin showed no differences in adverse events (bleeding, rash, hematoma, or bruising); the main finding was greater platelet function inhibition with dual therapy. Two fair-quality RCTs assessed other antiplatelet comparisons (aspirin or iloprost versus no antiplatelet agent, n=38; and aspirin 1000 mg versus aspirin 10 mg, n=216) in IC and CLI patients after PTA. Both RCTs reported no differences in vessel patency or restenosis between the treatment groups and were underpowered.

Four RCTs reported subgroup analyses of demographic or clinical factors that modify the effect of antiplatelet agents in PAD and involved a total of 5053 patients. Two of these RCTs included asymptomatic or symptomatic patients, and two included patients with either IC or CLI. Subgroups analyzed included diabetes (one RCT), age (one RCT), sex (two RCT), and PAD characteristics (two studies assessing ABI or type of bypass graft). The small number of and variation in subgroup analyses precluded the calculation of any overall estimate. One study of patients with IC or CLI showed a benefit of clopidogrel plus aspirin for reducing composite vascular events in patients with a prosthetic bypass graft compared to those with a venous bypass graft. Another study showed similar clinical outcomes in men and women treated with antiplatelet agents.

Seven RCTs reported safety concerns from antiplatelet treatment in the PAD population and involved a total of 8297 patients. All seven studies reported bleeding—GI bleeding, transfusion, any bleeding—as a harm. In general, use of antiplatelet agents was associated with higher rates of minor and moderate bleeding compared with placebo, ranging from 2 to 4 percent with aspirin, 2 percent with dual antiplatelet (no procedure), and 16.7 percent with dual antiplatelet (postbypass grafting).

Table 32 summarizes the SOE for the outcomes of all-cause mortality, nonfatal MI, nonfatal stroke, and composite vascular events. No studies reported results on functional outcomes or quality of life. Very few studies reported modifiers of effectiveness or safety outcomes.

Table 32 Summary SOE for KQ 1: Comparative effectiveness and safety of antiplatelet therapy for adults with PAD^a^

Comparison | Population | Outcome SOE | Results or Effect Estimate (95% Confidence Interval)
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years | Asymptomatic population | All-cause mortality SOE=High | 2 RCTs, 3,986 patients HR 0.93 (0.71 to 1.24) HR 0.95 (0.77 to 1.16) No difference
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years | | Nonfatal MI SOE=High | 2 RCTs, 3,986 patients HR 0.98 (0.68 to 1.42) HR 0.91 (0.65 to 1.29) No difference
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years | | Nonfatal stroke SOE=High | 2 RCTs, 3,986 patients HR 0.71 (0.44 to 1.14) HR 0.97 (0.62 to 1.53) No difference
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years | | Cardiovascular mortality SOE=Moderate | 2 RCTs, 3,986 patients HR 1.23 (0.79 to 1.92) HR 0.95 (0.77 to 1.17) No difference
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years | | Composite vascular events SOE=High | 2 RCTs, 3,986 patients HR 0.98 (0.76 to 1.26) HR 1.00 (0.85 to 1.17) No difference
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years | | Functional outcomes Quality of life Safety concerns (subgroups) SOE=Insufficient | 0 studies
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years | | Modifiers of effectiveness (subgroups) SOE=Insufficient | 2 RCTs, 3,986 patients Inconclusive evidence due to imprecision, with 1 study reporting similar rates of cardiovascular outcomes by age, sex, or baseline ABI and 1 study reporting similar rates of cardiovascular mortality and stroke by diabetic status.
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years | | Safety concerns SOE=Insufficient | 2 RCTs, 3,986 patients Inconclusive evidence due to heterogeneous results between aspirin and placebo in regard to major hemorrhage and GI bleeding rates.
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years | IC population | Nonfatal MI SOE=Low | 1 RCT, 181 patients HR 0.18 (0.04 to 0.82) Favors aspirin.
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years | | Nonfatal stroke SOE=Insufficient | 1 RCT, 181 patients HR 0.54 (0.16 to 1.84) Inconclusive evidence due to imprecision.
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years | | Cardiovascular mortality SOE=Insufficient | 1 RCT, 181 patients HR 1.21 (0.32 to 4.55) Inconclusive evidence due to imprecision.
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years | | Composite vascular events SOE=Low | 1 RCT, 181 patients HR 0.35 (0.15 to 0.82) Favors aspirin
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years | | Functional outcomes Quality of life Safety concerns (subgroups SOE=Insufficient | 0 studies
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years | | Modifiers of effectiveness (subgroups) SOE=Insufficient | 1 RCT, 216 patients Inconclusive evidence due to imprecision, with 1 study reporting similar rates in vessel patency by sex.
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years | | Safety concerns SOE=Insufficient | 1 RCT, 181 patients Inconclusive evidence due to imprecision, with 1 study reporting a bleeding rate of 3% in aspirin group and 0% in placebo group.
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years | CLI population | Nonfatal MI SOE=Insufficient | 1 observational study, 113 patients Inconclusive evidence due to imprecision, with 1 study reporting MI rate of 1.2% in aspirin group and 5.9% in no-aspirin group.
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years | | Nonfatal stroke SOE=Insufficient | 1 observational study, 113 patients Inconclusive evidence due to imprecision, with 1 study reporting stroke rate of 2.5% in aspirin group and 8.8% in no-aspirin group.
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years | | Cardiovascular mortality SOE=Insufficient | 1 observational study, 113 patients Inconclusive evidence due to imprecision, with 1 study reporting cardiovascular mortality rate of 33% in aspirin group and 26% in no-aspirin group..
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years
Aspirin vs. placebo in adults with asymptomatic or symptomatic PAD at 2+ years | | Functional outcomes Quality of life Modifiers of effectiveness (subgroups) Safety concerns Safety concerns (subgroups) SOE=Insufficient | 0 studies
Clopidogrel vs. aspirin in adults with IC at 2 years (CAPRIE) | | Nonfatal MI SOE=Moderate | 1 RCT, 6,452 patients HR 0.62 (0.43 to 0.88) Favors clopidogrel
Clopidogrel vs. aspirin in adults with IC at 2 years (CAPRIE)
Clopidogrel vs. aspirin in adults with IC at 2 years (CAPRIE) | | Nonfatal stroke SOE=Low | 1 RCT, 6,452 patients HR 0.95 (0.68 to 1.31) No difference
Clopidogrel vs. aspirin in adults with IC at 2 years (CAPRIE)
Clopidogrel vs. aspirin in adults with IC at 2 years (CAPRIE) | | Cardiovascular mortality SOE=Moderate | 1 RCT, 6,452 patients HR 0.76 (0.64 to 0.91) Favors clopidogrel.
Clopidogrel vs. aspirin in adults with IC at 2 years (CAPRIE)
Clopidogrel vs. aspirin in adults with IC at 2 years (CAPRIE) | | Composite cardiovascular events SOE=Moderate | 1 RCT, 6,452 patients HR 0.78 (0.65 to 0.93) Favors clopidogrel.
Clopidogrel vs. aspirin in adults with IC at 2 years (CAPRIE)
Clopidogrel vs. aspirin in adults with IC at 2 years (CAPRIE) | | All-cause mortality Functional outcomes Quality of life Modifiers of effectiveness (subgroups) Safety concerns Safety concerns (subgroups) SOE=Insufficient | 0 studies
Clopidogrel/aspirin vs. aspirin in adults with PAD at 2 years
Clopidogrel/aspirin vs. aspirin in adults with PAD at 2 years
Clopidogrel/aspirin vs. aspirin in adults with PAD at 2 years | Symptomatic–asymptomatic population (CHARISMA) | All-cause mortality SOE=Moderate | 1 RCT, 3,096 patients HR 0.89 (0.68 to 1.16) No difference.
Clopidogrel/aspirin vs. aspirin in adults with PAD at 2 years
Clopidogrel/aspirin vs. aspirin in adults with PAD at 2 years | | Nonfatal MI SOE=Low | 1 RCT, 3,096 patients HR 0.63 (0.42 to 0.95) Favors dual antiplatelet.
Clopidogrel/aspirin vs. aspirin in adults with PAD at 2 years
Clopidogrel/aspirin vs. aspirin in adults with PAD at 2 years | | Nonfatal stroke SOE=Low | 1 RCT, 3,096 patients HR 0.79 (0.51 to 1.22) No difference.
Clopidogrel/aspirin vs. aspirin in adults with PAD at 2 years
Clopidogrel/aspirin vs. aspirin in adults with PAD at 2 years | | Cardiovascular mortality SOE=Low | 1 RCT, 3,096 patients HR 0.92 (0.66 to 1.29) No difference.
Clopidogrel/aspirin vs. aspirin in adults with PAD at 2 years
Clopidogrel/aspirin vs. aspirin in adults with PAD at 2 years | | Composite cardiovascular events SOE=Moderate | 1 RCT, 3,096 patients HR 0.85 (0.66 to 1.09) No difference.
Clopidogrel/aspirin vs. aspirin in adults with PAD at 2 years
Clopidogrel/aspirin vs. aspirin in adults with PAD at 2 years | | Functional outcomes Quality of life Safety concerns (subgroups) Modifiers of effectiveness (subgroups) SOE=Insufficient | 0 studies
Clopidogrel/aspirin vs. aspirin in adults with PAD at 2 years
Clopidogrel/aspirin vs. aspirin in adults with PAD at 2 years | | Safety concerns SOE=Insufficient | 1 RCT, 3,096 patients Inconclusive evidence due to low rates of severe and moderate bleeding, although minor bleeding was significantly higher with DAPT (34.4%) vs. ASA (20.8%).
Clopidogrel/aspirin vs. aspirin in adults with PAD at 2 years
Clopidogrel/aspirin vs. aspirin in adults with PAD at 2 years | IC–CLI population (CASPAR, MIRROR, Cassar) | All-cause mortality SOE=Insufficient | 2 RCTs, 931 patients CASPAR, HR 1.44 (0.77 to 2.69) MIRROR, OR 0.33 (0.01 to 8.22) Inconclusive evidence due to imprecision.
Clopidogrel/aspirin vs. aspirin in adults with PAD at 2 years
Clopidogrel/aspirin vs. aspirin in adults with PAD at 2 years | | Nonfatal MI SOE=Insufficient | 1 RCT, 851 patients CASPAR, HR 0.81 (0.32 to 2.06) Inconclusive evidence due to imprecision.
Clopidogrel/aspirin vs. aspirin in adults with PAD at 2 years
Clopidogrel/aspirin vs. aspirin in adults with PAD at 2 years | | Nonfatal stroke SOE=Low | 1 RCT, 851 patients CASPAR, HR 1.02 (0.41 to 2.55) No difference.
Clopidogrel/aspirin vs. aspirin in adults with PAD at 2 years
Clopidogrel/aspirin vs. aspirin in adults with PAD at 2 years | | Cardiovascular mortality SOE=Insufficient | 1 RCT, 851 patients CASPAR, HR 1.44 (0.77 to 2.69) Inconclusive evidence due to imprecision.
Clopidogrel/aspirin vs. aspirin in adults with PAD at 2 years
Clopidogrel/aspirin vs. aspirin in adults with PAD at 2 years | | Composite cardiovascular events | 2 RCTs, 931 patients CASPAR, HR 1.09 (0.65 to 1.82), No difference
Clopidogrel/aspirin vs. aspirin in adults with PAD at 2 years | | SOE=Low (CASPAR) SOE=Insufficient (MIRROR) | MIRROR, OR 0.71 (0.28 to 1.81), Inconclusive evidence due to imprecision.
Clopidogrel/aspirin vs. aspirin in adults with PAD at 2 years
Clopidogrel/aspirin vs. aspirin in adults with PAD at 2 years | | Functional outcomes Quality of life Safety concerns (subgroups) SOE=Insufficient | 0 studies
Clopidogrel/aspirin vs. aspirin in adults with PAD at 2 years
Clopidogrel/aspirin vs. aspirin in adults with PAD at 2 years | | Modifiers of effectiveness (subgroups) SOE=Insufficient | 1 RCT, 851 patients Inconclusive evidence due to imprecision, with 1 study reporting that patients with prosthetic graft had lower cardiovascular events on DAPT.
Clopidogrel/aspirin vs. aspirin in adults with PAD at 2 years
Clopidogrel/aspirin vs. aspirin in adults with PAD at 2 years | | Safety concerns SOE=Insufficient | 3 RCTs, 1,034 patients Inconclusive evidence due to inconsistent results from individual studies: CASPAR study showed statistically significant higher rates of moderate and minor bleeding with DAPT; Cassar study showed more bruising with DAPT but no significant difference in gastrointestinal bleeding or hematoma; MIRROR study showed no significant difference in bleeding.

a Gray highlights insufficient strength of evidence.

Abbreviations: ABI=ankle-brachial index; CLI=critical limb ischemia; DAPT=dual antiplatelet therapy; HR=hazard ratio; IC=intermittent claudication; MI=myocardial infarction; OR=odds ratio; RCT=randomized controlled trial; SOE=strength of evidence

### KQ 2 Comparative Effectiveness and Safety of Exercise, Medications, and Endovascular and Surgical Revascularization for IC

Thirty-five (27 RCT, 8 observational; 7475 patients) evaluated the effectiveness of exercise, medical therapy, endovascular or surgical revascularization for IC. The following comparisons were assessed in the included studies: (1) medical therapy (cilostazol) versus placebo (10 RCTs; 4103 total patients); (2) exercise training versus usual care (10 RCTs, two observational; 754 total patients); (3) endovascular intervention versus usual care (5 RCTs, 4 observational; 1593 total patients); (4) surgical revascularization versus usual care (1 observational; 427 total patients); (5) endovascular intervention versus exercise training (9 RCTs; 1005 total patients); (6) surgical revascularization versus exercise training plus medical therapy (1 observational; 127 total patients); and (7) endovascular versus surgical revascularization (3 observational studies; 421 total patients). A majority of the endovascular procedures consisted of PTA with or without stent placement, and the type of stent was not specified. Differences in the treatment comparisons, measures, and followup time points reduced the number of studies that could be pooled for analysis of direct comparisons.

In a random-effects meta-analysis of 12 RCTs that compared the effect of multiple treatments on all-cause mortality, no specific treatment was found to have a statistically significant effect.

In a random-effects meta-analysis of 16 RCTs that compared the effect of multiple treatments on MWD or ACD, exercise training was associated with a statistically significant improvement when compared with usual care; endovascular intervention was associated with a statistically significant improvement in ACD when compared with usual care. None of the other treatments were found to have a statistically significant effect when compared with usual care or against each other. A sensitivity analysis removing the pentoxifylline studies (due to inconsistency and imprecision) resulted in effect size estimates that are slightly increased for the remaining treatment modalities. Studies that measured peak walking time rather than distance showed similar results across treatment comparisons.

In a random-effects meta-analysis of 12 RCTs that compared the effect of multiple treatments on initial claudication distance or pain-free walking distance, cilostazol was associated with a statistically nonsignificant improvement when compared with usual care; however, exercise training and endovascular revascularization was associated with a statistically significant improvement when compared with usual care. When directly compared in head-to-head studies, there was no difference between the three treatments. Again, studies not included in the meta-analysis due to measurement of claudication onset time rather than distance found similar results across treatment comparisons.

A meta-analysis of 13 RCTs examining the difference in the SF-36 measure of physical functioning among exercise training, endovascular intervention, and usual care measured between 3 months and 6 months showed a significant improvement in quality of life from cilostazol, exercise training, endovascular intervention, and surgical revascularization compared with usual care. However, the comparisons of all active treatments with each other showed that none of the treatments are significantly different from each other.

Vessel patency, repeat revascularization, wound healing, analog pain scale score, cardiovascular events (e.g., all-cause mortality, MI, stroke, cardiovascular death), and amputation were infrequently reported.

Six studies (4 RCTs, 2 observational) reported variations in the treatment effectiveness by subgroup including severity of symptoms, functional limitations, anatomic location of disease, and success of revascularization. There were no studies reporting results by the following subgroups: age, sex, race, presence of diabetes mellitus or renal disease, smoking status, or prior revascularization. Despite limited data to draw definitive conclusions, one study reported improvements in quality-of-life measures and ABI in patients with successful endovascular revascularization when compared with patients without successful endovascular revascularization. Another study reported improvement in ABI in patients with successful surgical revascularization when compared with patients treated with exercise and medical therapy. One other study reported a statistically nonsignificant improvement in MWD favoring exercise training over endovascular revascularization in patients with SFA stenosis when compared with patients with iliac stenosis. Last, a single study reported variability in the patency of surgical revascularization based on anatomic location and graft type.

Seventeen RCTs reported safety concerns. A single study of exercise therapy versus usual care did not identify side effects from exercise. Studies of cilostazol had higher rates of headache, dizziness, and diarrhea. Studies of endovascular interventions reported more transfusions, arterial dissection/perforation, and hematomas compared to the usual care groups but the complication rates were low (1 to 2%). No studies were identified that measured contrast nephropathy, radiation, infection, or exercise-related harms. No studies reported on whether any of the harms vary by subgroup (age, sex, race, risk factors, comorbidities, anatomic location of disease).

Table 33 summarizes the SOE for the outcomes outlined in the KQ by each treatment strategy. We found very few studies that assessed cardiovascular outcomes (all-cause or cardiovascular mortality, nonfatal MI, nonfatal stroke, or composite events); therefore, the evidence base is insufficient for us to draw any conclusions on these outcomes. Similar to KQ 1, very few studies reported modifiers of effectiveness or safety outcomes.

Table 33 Summary SOE for KQ 2: Comparative effectiveness and safety of treatments for IC^a^

Comparison | Outcome SOE | Results or Effect Estimate (95% Confidence Interval)
Medical therapy vs. usual care | All-cause mortality SOE=Low | 4 RCTs, 2,732 patients OR 0.91 (0.62 to 1.35) No difference.
Medical therapy vs. usual care | Nonfatal MI SOE=Insufficient | 2 RCTs, 497 patients Inconclusive evidence due to low event rates in both groups.
Medical therapy vs. usual care | Nonfatal stroke SOE=Insufficient | 3 RCTs, 1,932 patients Inconclusive evidence due to low event rates in both groups.
Medical therapy vs. usual care | Amputation SOE=Insufficient | 2 RCTs, 497 patients Inconclusive evidence due to sparse data, with only 1 patient who underwent amputation in the 2 RCTs.
Medical therapy vs. usual care | Quality of life SOE=Low | 2 RCTs, 631 patients ES: 0.44 (0.05 to 0.83) Favors cilostazol.
Medical therapy vs. usual care | MWD or ACD SOE=Low (cilostazol) SOE=Insufficient (pentoxifylline) | Cilostazol (6 RCTs, 1,632 patients) ES: 0.62 (-0.21 to 1.45) full model; 0.61 (-0.20 to 1.42) sensitivity analysis No difference. Pentoxifylline (3 RCTs, 797 patients) ES: 1.70 (0.36 to 3.04) full model Inconclusive evidence due to imprecision.
Medical therapy vs. usual care | Initial claudication distance or pain-free walking distance SOE=Low (cilostazol) | 5 RCTs, 1,255 patients ES: 0.63 (-0.03 to 1.29) No difference.
Medical therapy vs. usual care | Modifiers of effectiveness (subgroups) SOE=Insufficient | 2 RCTs, 155 patients Inconclusive evidence due to individual studies reporting different endpoints.
Medical therapy vs. usual care | Safety concerns SOE=High (headache) SOE=Moderate (diarrhea) SOE=Moderate (palpitations) | Higher side effects on cilostazol Headache 10 RCTs, 3,485 patients OR 3.00 (2.29 to 3.95) Diarrhea 10 RCTs, 3,485 patients OR 2.51 (1.58 to 3.97) Palpitations 10 RCTs, 3,485 patients OR 18.11 (5.95 to 55.13)
Medical therapy vs. usual care | Primary patency Secondary patency Composite cardiovascular events Wound healing Analog pain scale Safety concerns (subgroups) SOE=Insufficient | 0 studies
Exercise training vs. usual care | All-cause mortality SOE=Low | 2 RCTs, 238 patients OR 0.84 (0.34 to 2.07) No difference.
Exercise training vs. usual care | Nonfatal MI SOE=Insufficient | 1 RCT, 63 patients Inconclusive evidence due to sparse data, with only 1 MI in exercise group.
Exercise training vs. usual care | Nonfatal stroke SOE=Insufficient | 1 RCT, 63 patients Inconclusive evidence due to sparse data, with only 1 stroke in each group.
Exercise training vs. usual care | Amputation SOE=Insufficient | 1 RCT; 31 patients Inconclusive evidence due to sparse data, with only 1 patient who underwent amputation.
Exercise training vs. usual care | Quality of life SOE=Low | 4 RCTs, 1 observational study, 275 patients ES: 0.56 (0.26 to 0.87) Favors exercise.
Exercise training vs. usual care | MWD or ACD SOE=Moderate | 9 RCTs, 2 observational studies, 624 patients ES: 0.89 (0.06 to 1.71) full model; 0.98 (0.23 to 1.74) sensitivity analysis Favors exercise.
Exercise training vs. usual care | Initial claudication distance or pain-free walking distance SOE=Low | 9 RCTs, 1 observational studies, 396 patients ES: 0.69 (0.22 to 1.15) Favors exercise.
Exercise training vs. usual care | Safety concerns SOE=Insufficient | 3 RCTs, 107 patients Inconclusive evidence due to sparse data, with studies reporting no adverse events in exercise or usual care groups.
Exercise training vs. usual care | Composite cardiovascular events Wound healing Analog pain scale Safety concerns (subgroups) SOE=Insufficient | 0 studies
Endovascular intervention vs. usual care | All-cause mortality SOE=Low | 2 RCTs, 3 observational studies, 977 patients OR 0.91 (0.34 to 2.45) No difference.
Endovascular intervention vs. usual care | Nonfatal MI SOE=Insufficient | 1 observational study; 479 patients Inconclusive evidence due to imprecision, with 1 study reporting 3.0% in endovascular group and 8.8% in usual care group.
Endovascular intervention vs. usual care | Nonfatal stroke SOE=Insufficient | 2 observational studies; 800 patients Inconclusive evidence due to sparse data, with 1 study reporting 4 strokes for total study, and 1 study reporting 1 stroke in endovascular group, 2 strokes in usual care group.
Endovascular intervention vs. usual care | Amputation SOE=Insufficient | 1 RCT, 1 observational study, 73 patients Inconclusive evidence due to imprecision, with 1 study reporting similar amputation rates in the endovascular and usual care groups.
Endovascular intervention vs. usual care | Quality of life SOE=Low | 2 RCTs, 2 observational studies, 576 patients ES: 0.61 (0.30 to 0.93) Favors endovascular intervention.
Endovascular intervention vs. usual care | MWD or ACD SOE=Low | 4 RCTs, 285 patients ES: 0.41 (-0.54 to 1.36) full model; 0.51 (-0.35 to 1.37) sensitivity analysis No difference.
Endovascular intervention vs. usual care | Initial claudication distance or pain-free walking distance SOE=Low | 5 RCTs, 281 patients ES: 0.79 (0.29 to 1.29) Favors endovascular intervention.
Endovascular intervention vs. usual care | Modifiers of effectiveness (subgroups) SOE=Insufficient | 1 observational study, 526 patients Inconclusive evidence due to imprecision, with 1 study reporting better quality-of-life scores if ABI improvement was >0.1 after successful revascularization.
Endovascular intervention vs. usual care | Safety concerns SOE=Insufficient | 2 RCTs, 155 patients Inconclusive evidence due to sparse data, with 1 study reporting no events, and 1 study reporting low rates of transfusion, dissection, and perforation in the endovascular group.
Endovascular intervention vs. usual care | Composite cardiovascular events Wound healing Analog pain scale Safety concerns (subgroups) SOE=Insufficient | 0 studies
Surgical revascularization vs. usual care | All-cause mortality SOE=Insufficient | 1 observational study, 427 patients Inconclusive evidence due to imprecision, with mortality rates of 10.4% in surgical group and 16.7% in usual care group.
Surgical revascularization vs. usual care | Quality of life SOE=Low | 2 observational studies, 727 patients ES: 0.82 (0.26 to 1.39) Favors surgery.
Surgical revascularization vs. usual care | Primary patency Secondary patency SOE=Insufficient | 1 observational study, 427 patients Inconclusive evidence due to imprecision, with 1 study reporting vessel patency only in patients undergoing revascularization (aortofemoral bypass 95.5%, axillofemoral bypass 83.3%, femorofemoral bypass 95.5%, femoropopliteal bypass [AK] 67.6%, femorofemoral bypass [BK] 45.2%).
Surgical revascularization vs. usual care | Modifiers of effectiveness (subgroups) SOE=Insufficient | 1 observational study, 427 patients Inconclusive evidence due to results from 1 study where patency rates were significantly lower for infrainguinal bypass and synthetic graft vs. suprainguinal and autologous vein graft.
Surgical revascularization vs. usual care | Nonfatal MI Nonfatal stroke Amputation Composite cardiovascular events Wound healing Analog pain scale Safety concerns (subgroups) SOE=Insufficient | 0 studies
Endovascular intervention vs. exercise training | All-cause mortality SOE=Low | 5 RCTs, 710 patients OR 0.77 (0.39 to 1.54) No difference.
Endovascular intervention vs. exercise training | Nonfatal MI SOE=Insufficient | 1 RCT, 106 patients Inconclusive evidence due to sparse data, with no events occurring in either treatment group.
Endovascular intervention vs. exercise training | Nonfatal stroke SOE=Insufficient | 1 RCT, 106 patients Inconclusive evidence due to sparse data, with only 1 stroke in each group.
Endovascular intervention vs. exercise training | Amputation SOE=Insufficient | 1 RCT, 149 patients Inconclusive evidence due to sparse data, with 1 amputation in endovascular group and none in exercise group.
Endovascular intervention vs. exercise training | Quality of life SOE=Low | 4 RCTs, 444 patients ES: 0.05 (-0.24 to 0.34) No difference.
Endovascular intervention vs. exercise training | MWD or ACD SOE=Moderate | 4 RCTs, 695 patients ES: -0.47 (-1.41 to 0.46) full model; -0.47 (-1.31 to 0.36) sensitivity analysis No difference.
Endovascular intervention vs. exercise training | ICD or PFWD SOE=Low | 5 RCTs, 448 patients ES: 0.10 (-0.38 to 0.58) No difference.
Endovascular intervention vs. exercise training | Modifiers of effectiveness (subgroups) SOE=Insufficient | 1 RCT, 56 patients Inconclusive evidence due to indirect results from 1 study reporting a statistically nonsignificant improvement in MWD in patients with superficial femoral artery (SFA) disease treated with percutaneous transluminal angioplasty ( PTA).
Endovascular intervention vs. exercise training | Safety concerns SOE=Insufficient | 5 RCTs, 282 patients Inconclusive evidence due to heterogeneity of reporting, with individual studies reporting that endovascular interventions were associated with higher rates of transfusion, dissection/perforation, and hematomas.
Endovascular intervention vs. exercise training | Composite cardiovascular events Wound healing Analog pain scale Safety concerns (subgroups) SOE=Insufficient | 0 studies
Surgical intervention vs. exercise + medical therapy (pentoxifylline) | MWD or ACD SOE=Insufficient | 1 observational study, 127 patients Inconclusive evidence due to imprecision, with 1 study reporting that MWT improved to >15 min in surgical group and >11 min in exercise plus medical therapy group.
Surgical intervention vs. exercise + medical therapy (pentoxifylline) | Initial claudication distance or pain-free walking distance SOE=Insufficient | 1 observational study, 127 patients Inconclusive evidence due to imprecision, with 1 study reporting that COT improved to >10 min in surgical group and >7 min in exercise plus medical therapy group.
Surgical intervention vs. exercise + medical therapy (pentoxifylline) | Composite cardiovascular events Wound healing Analog pain scale Safety concerns (subgroups) SOE=Insufficient | 0 studies
Endovascular intervention vs. surgical revascularization | All-cause mortality SOE=Insufficient | 2 observational studies, 305 patients Inconclusive evidence due to inadequate reporting, with neither study reporting results by treatment group; overall mortality rate ranged from 3 to 8%.
Endovascular intervention vs. surgical revascularization | Quality of life SOE=Low | 2 observational studies, 242 patients ES: 0.21 (-0.34 to 0.76) No difference.
Endovascular intervention vs. surgical revascularization | MWD or absolute claudication distance SOE=Insufficient | 0 studies
Endovascular intervention vs. surgical revascularization | ICD or PFWD SOE=Insufficient | 0 studies
Endovascular intervention vs. surgical revascularization | Modifiers of effectiveness (subgroups) SOE=Insufficient | 1 RCT, 264 patients Inconclusive evidence due to indirect results from 1 study, with similar patency rates for suprainguinal and infrainguinal reconstruction.
Endovascular intervention vs. surgical revascularization | Nonfatal MI Nonfatal stroke Amputation Primary patency Secondary patency Composite cardiovascular events Wound healing Analog pain scale Safety concerns (subgroups) SOE=Insufficient | 0 studies
Endovascular intervention + exercise training vs. usual care | MWD or ACD SOE=Low | 2 RCTs, 248 patients ES: 1.08 (-0.37 to 2.53) full model; 1.20 (-0.11 to 2.50) sensitivity analysis Favors endovascular intervention plus exercise training.
Endovascular intervention + exercise training vs. usual care | Composite cardiovascular events Wound healing Analog pain scale Safety concerns (subgroups) SOE=Insufficient | 0 studies
Exercise training vs. invasive therapy vs. usual care | Primary patency Secondary patency SOE=Insufficient | 1 RCT, 225 patients Inconclusive evidence due to biased reporting where vessel patency was only reported in patients undergoing revascularization (endovascular group 59%, surgical group 98%).
Exercise training vs. invasive therapy vs. usual care | Composite cardiovascular events Wound healing Analog pain scale Safety concerns (subgroups) SOE=Insufficient | 0 studies

a Grey background indicates insufficient SOE.

Abbreviations: ACD=absolute claudication distance; ES=effect size; ICD=initial claudication distance; MI=myocardial infarction; MWD=maximal walking distance; OR=odds ratio; PFWD=pain-free walking distance; PTA=percutaneous transluminal angioplasty; RCT=randomized controlled trial; SFA=superficial femoral artery; SOE=strength of evidence.

### KQ 3 Comparative Effectiveness and Safety of Usual Care and Endovascular and Surgical Revascularization for CLI

We identified 37 unique studies (3 RCT, 34 observational) that evaluated the comparative effectiveness of usual care, endovascular intervention, and surgical revascularization in CLI or IC-CLI patients. Of these, four observational studies compared usual care with endovascular intervention. Of the 37 studies, 23 (1 RCT, 22 observational) evaluated the comparative effectiveness of endovascular and surgical revascularization in 12,779 patients with CLI, and 12 (2 RCT, 10 observational) evaluated the comparative effectiveness of endovascular and surgical revascularization in a mixed population of 565,168 PAD patients with either IC or CLI. The clinical outcomes of interest included vessel patency, repeat revascularization, wound healing, analog pain scale score, cardiovascular events (e.g., all-cause mortality, MI, stroke, cardiovascular death), amputation, functional capacity, and quality of life.

In the four observational studies that compared endovascular interventions with usual care, the reported outcomes included mortality (four studies), amputation/limb salvage (four studies), amputation-free survival (one study), and hospital length of stay (two studies). Most clinical outcomes were improved with endovascular therapy however the results were nonsignificant and inconsistent. None of these studies reported the rates of stroke, MI, functional outcomes, quality of life, vessel patency, wound healing, pain scores, subgroup differences, or harms. Similar to KQ 2, a majority of the endovascular procedures consisted of PTA with or without stent placement, and the type of stent was not specified.

Meta-analysis of endovascular versus surgical revascularization studies showed all-cause mortality was not different between patients treated with endovascular versus surgical revascularization although endovascular interventions did demonstrate a statistically nonsignificant benefit in all-cause mortality at less than 6 months in the CLI and IC-CLI populations and at 1 to 2 years in the IC-CLI population. Evidence regarding patency rates varied, but secondary patency rates demonstrated a benefit of endovascular interventions compared with surgical revascularization across all followup time points in the CLI population. There were few studies that assessed functional outcomes, quality of life, or cardiovascular outcomes (cardiovascular mortality, nonfatal stroke, nonfatal MI, or composite events). Fourteen studies reported hospital length of stay during the index hospitalization. The range of hospital stay was 1 to 15 days in the endovascular group and 2 to 37 days in the surgical group.

Variations in treatment effectiveness by subgroup were reported in 14 studies (2 RCT, 12 observational; 7 CLI and 7 IC-CLI populations). Subgroups reported included age (three studies), symptom class (three studies), renal failure (two studies), anatomic factors (four studies), type of vein graft (two studies), and one study each on diabetes, smoking status, hyperlipidemia, and hypertension. In the single RCT of CLI patients, the use of autologous vein was associated with improved outcomes when compared with prosthetic conduit. Additionally, the performance of subintimal angioplasty was associated with statistically nonsignificant worse outcomes when compared with standard angioplasty. Data derived from the observational studies had a high likelihood of bias but did show that with advanced age, renal failure, and higher Rutherford classification, patients generally fared worse in terms of mortality and amputation.

Only one observational study in the CLI population reported safety concerns. Specifically, this study reported the incidence of thrombosis at 30 days and found that the risk of thrombosis was higher in patients undergoing surgical revascularization than in patients undergoing endovascular revascularization. Six studies (2 RCT, 4 observational) in the mixed IC-CLI population reported harms of bleeding, infection, renal dysfunction, or periprocedural complications causing acute limb ischemia. There were conflicting results in the summary estimates for periprocedural complications in the IC-CLI population with the observational studies showing lower rates in those who received an endovascular intervention and RCTs showing lower rates in the surgical population; however the wide confidence intervals make the differences nonsignificant. Infection was more common in the surgical intervention arm based on three studies.

Table 34 summarizes the SOE for the outcomes from the endovascular versus surgical revascularization studies. We found very few studies that assessed functional outcomes, quality of life, or cardiovascular outcomes (cardiovascular mortality, nonfatal MI, nonfatal stroke, or composite events), therefore the evidence base is insufficient for us to draw any conclusions on these outcomes. Like the other KQs, very few studies reported modifiers of effectiveness or safety outcomes.

Table 34 Summary SOE for KQ 3: Comparative effectiveness and safety of treatments for CLI^a^

Comparison | Outcome SOE | Results or Effect Estimate (95% Confidence Interval)
Endovascular intervention vs. usual care in CLI and IC-CLI populations | All-cause mortality SOE=Insufficient | CLI-Obs (3 studies, 562 patients) Inconclusive evidence due to imprecision. IC-CLI-Obs (1 study, 107 patients) Inconclusive evidence due to imprecision, with 1 study reporting similar mortality rates.
Endovascular intervention vs. usual care in CLI and IC-CLI populations | Amputation SOE=Insufficient | CLI-Obs (3 studies, 562 patients) Inconclusive evidence due to heterogeneity in reporting amputation rates across studies. IC-CLI-Obs (1 study, 107 patients) Inconclusive evidence due to imprecision, with 1 study reporting a nonsignificant difference.
Endovascular intervention vs. usual care in CLI and IC-CLI populations | Amputation-free survival SOE=Insufficient | CLI-Obs (1 study, 70 patients) Inconclusive evidence due to imprecision, with 1 study reporting AFS rates (endovascular group 60%, usual care 47%).
Endovascular intervention vs. usual care in CLI and IC-CLI populations | Length of stay SOE=Insufficient | CLI-Obs (3 studies, 562 patients) Inconclusive evidence due to inconsistent and imprecise results across studies.
Endovascular intervention vs. usual care in CLI and IC-CLI populations | Nonfatal stroke Nonfatal MI Composite cardiovascular events MWD or absolute claudication distance Initial claudication distance or pain-free walking distance Quality of life Primary patency Secondary patency Wound healing Analog pain scale Modifiers of effectiveness (subgroups) Safety concerns Safety concerns (subgroups) SOE=Insufficient | All PAD populations and study design (0 studies)
Endovascular vs. surgical revascularization in CLI and IC-CLI populations | All-cause mortality less than or equal to 6 months SOE=Low | CLI-Obs (11 studies, 8,249 patients), OR 0.85 (0.57 to 1.27) CLI-RCT (1 study, 452 patients), OR 0.51 (0.20 to 1.35) Favors endovascular. IC-CLI-Obs (2 studies, 823 patients), OR 0.45 (0.18 to 1.09) Favors endovascular.
Endovascular vs. surgical revascularization in CLI and IC-CLI populations | All-cause mortality at 1 to 2 years SOE=Low | CLI-Obs (12 studies, 7,850 patients), OR 1.01 (0.80 to 1.28) No difference. IC-CLI-Obs (2 studies, 145 patients), OR 0.51 (0.20 to 1.31) IC-CLI-RCT (2 studies, 130 patients), OR 0.81 (0.23 to 2.82) Favors endovascular.
Endovascular vs. surgical revascularization in CLI and IC-CLI populations | All-cause mortality at 3 or more years SOE=Low (CLI) SOE=Insufficient (IC-CLI) | CLI-Obs (7 studies, 7,176 patients), OR 1.05 (0.54 to 2.06) CLI-RCT (1 study, 452 patients), OR 1.07 (0.73 to 1.56) No difference. IC-CLI-RCT (1 study, 58 patients) OR 0.88 (0.28 to 2.73) Inconclusive evidence due to imprecision.
Endovascular vs. surgical revascularization in CLI and IC-CLI populations | Nonfatal MI SOE=Insufficient | CLI-RCT (1 study, 452 patients) Inconclusive evidence due to imprecision, with 1 study reporting MI rates (endovascular group 3% and surgical group 8%).
Endovascular vs. surgical revascularization in CLI and IC-CLI populations | Amputation at <2 years SOE=Low (CLI) SOE=Insufficient (IC-CLI) | CLI-Obs (11 studies, 4490 patients), OR 0.73 (0.48 to 1.09) CLI-RCT (1 study, 452 patients), OR 1.23 (0.72 to 2.11) No difference. IC-CLI-Obs (2 studies, 823 patients), OR 1.11 (0.40 to 3.05) IC-CLI-RCT (2 studies, 130 patients), OR 0.22 (0.05 to 1.07) Inconclusive evidence due to imprecision.
Endovascular vs. surgical revascularization in CLI and IC-CLI populations | Amputation at 2 to 3 years SOE=Low (CLI) SOE=Insufficient (IC-CLI) | CLI-Obs (4 studies, 3187 patients), OR 1.08 (0.62 to 1.89) CLI-RCT (1 study, 452 patients), OR 1.02 (0.64 to 1.63) No difference. IC-CLI-Obs (1 study, 169 patients), OR 1.00 (0.18 to 5.54) IC-CLI-RCT (1 study, 86 patients), OR 0.18 (0.02 to 1.29) Inconclusive evidence due to imprecision.
Endovascular vs. surgical revascularization in CLI and IC-CLI populations | Amputation after 5 years SOE=Low | CLI-Obs (7 studies, 3101 patients), OR 1.06 (0.70 to 1.59) No difference.
Endovascular vs. surgical revascularization in CLI and IC-CLI populations | Amputation-free survival at 1 year SOE=Low | CLI-Obs (2 studies, 1881 patients), OR 0.76 (0.48 to 1.21) CLI-RCT (1 study, 452 patients), OR 0.87 (0.58 to 1.30) No difference.
Endovascular vs. surgical revascularization in CLI and IC-CLI populations | Amputation-free survival at 2 to 3 years SOE=Low | CLI-Obs (3 studies, 1972 patients), OR 0.75 (0.53 to 1.09) CLI-RCT (1 study, 452 patients), OR 1.22 (0.84 to 1.77) No difference.
Endovascular vs. surgical revascularization in CLI and IC-CLI populations | Amputation-free survival after 5 years SOE=Low | CLI-Obs (4 studies, 2190 patients), OR 0.89 (0.59 to 1.34) No difference.
Endovascular vs. surgical revascularization in CLI and IC-CLI populations | Wound healing SOE=Insufficient | CLI-Obs (1 study, 91 patients) Inconclusive evidence due to imprecision, with 1 study reporting similar rates of wound healing in the surgical revascularization group (83%) and endovascular revascularization group (80%).
Endovascular vs. surgical revascularization in CLI and IC-CLI populations | Primary patency at 1 year SOE=Moderate (CLI) SOE=Low (IC-CLI) | CLI-Obs (5 studies, 890 patients), OR 0.63 (0.46 to 0.86) No difference. IC-CLI-Obs (3 studies, 328 patients), OR 0.71 (0.40 to 1.28) IC-CLI-RCT (2 studies, 130 patients), OR 0.40 (0.08 to 1.93) Favors endovascular intervention.
Endovascular vs. surgical revascularization in CLI and IC-CLI populations | Primary patency at 2 to 3 years SOE=Insufficient | CLI-Obs (4 studies, 768 patients), OR 0.77 (0.24 to 2.42) Inconclusive evidence due to imprecision. IC-CLI-Obs (2 studies, 231 patients), OR 0.29 (0.15 to 0.55) IC-CLI-RCT (1 study, 86 patients), OR 0.96 (0.42 to 2.16) Inconclusive evidence due to imprecision.
Endovascular vs. surgical revascularization in CLI and IC-CLI populations | Secondary patency at 1 year SOE=Low (CLI) SOE=Insufficient (IC-CLI) | CLI-Obs (4 studies, 759 patients), OR 0.57 to (0.40 to 0.82) Favors endovascular intervention. IC-CLI-RCT (1 study, 44 patients), OR 0.04 (0.00 to 0.73) Inconclusive evidence due to imprecision.
Endovascular vs. surgical revascularization in CLI and IC-CLI populations | Secondary patency at 2 to 3 years SOE=Low | CLI-Obs (4 studies, 815 patients), OR 0.49 (0.28 to 0.85) Favors endovascular intervention.
Endovascular vs. surgical revascularization in CLI and IC-CLI populations | Length of stay SOE=Insufficient | CLI-Obs (8 studies, 1745 patients) CLI-RCT (1 study, 452 patients) Inconclusive evidence due to inconsistency and imprecision, with individual studies reporting LOS longer in surgical group with large SD in 3 observational studies and no variability reported in 4 observational studies and one RCT. IC-CLI-Obs (3 studies, 563,935 patients) IC-CLI-RCT (2 studies, 130 patients) Inconclusive evidence due to imprecision, with individual studies reporting LOS longer in surgical group with large SD in the observational studies and RCTs.
Endovascular vs. surgical revascularization in CLI and IC-CLI populations | Modifiers of effectiveness (subgroups) SOE=Insufficient | All PAD populations and study design (14 studies, 572,188 patients) Inconclusive evidence due to heterogeneity in subgroups assessed across individual studies and inability to quantitatively synthesize results. One RCT showed higher survival in autologous vein graft compared with prosthetic graft. An observational study showed worse survival in advanced age, renal failure, and with higher PAD severity.
Endovascular vs. surgical revascularization in CLI and IC-CLI populations | Safety concerns: periprocedural complications SOE=Insufficient | IC-CLI-Obs (4 studies, 968 patients), OR 1.87 (0.63 to 5.49) IC-CLI-RCT (2 studies, 130 patients), OR 0.57 (0.14 to 2.26) Inconclusive evidence due to inconsistency and imprecision with observational studies favoring endovascular while the RCTs favor surgical revascularization.
Endovascular vs. surgical revascularization in CLI and IC-CLI populations | Safety concerns: infection SOE=Low | IC-CLI-Obs (2 studies, 823 patients), OR 14.10 (0.43 to 460.70) IC-CLI-RCT (1 study, 44 patients), OR 12.09 (0.61 to 239.54) Favors endovascular intervention.
Endovascular vs. surgical revascularization in CLI and IC-CLI populations | Nonfatal stroke Composite cardiovascular events MWD or absolute claudication distance Initial claudication distance or pain-free walking distance Quality of life Analog pain scale Safety concerns (subgroups) SOE=Insufficient | All PAD populations and study design (0 studies)

a Grey background indicates insufficient SOE.

Abbreviations: ACD=absolute claudication distance; CLI=critical limb ischemia; IC=intermittent claudication; ICD=initial claudication distance; MI=myocardial infarction; MWD=maximal walking distance; Obs=observational; PFWD=pain-free walking distance; RCT=randomized controlled trial; SOE=strength of evidence; yr=year(s).

## Findings in Relation to What Is Already Known

For KQ 1, which addresses antiplatelet therapy in PAD patients, our findings on the effectiveness of aspirin are similar to a meta-analysis of 18 studies published in 2009 by Berger et al.44 In the subset treated with aspirin alone compared with placebo, they found a nonsignificant reduction in cardiovascular events (defined as nonfatal MI, nonfatal stroke, and cardiovascular mortality; RR 0.75; 95% CI, 0.48 to 1.18); a significant reduction in nonfatal stroke (RR 0.64; CI, 0.42 to 0.99); and no statistically significant reductions in nonfatal MI, cardiovascular mortality, or major bleeding.

In this review, we excluded studies published prior to 1995 (n=15) and did not include studies with the combination of aspirin and dipyridamole (n=9). Also, 12 of the 18 studies in the previous meta-analysis44 were in patients who were treated prior to or after a revascularization procedure. We felt this represented a population with evidence of clinical disease and possible interaction with revascularization therapies. The study by Fowkes et al.56 was published after that meta-analysis and is the largest study of asymptomatic patients with PAD who have no established cardiovascular disease. Therefore, our review of three aspirin versus placebo studies54-56 contains the most recent evidence for the effectiveness of aspirin in an era where secondary prevention of cardiovascular events includes treatment of hypertension, diabetes, hyperlipidemia, and tobacco use with current guideline recommendations to reach specific blood pressure, hemoglobin A1c, and lipid-lowering goals as well as access to nicotine replacement therapy for smoking cessation. Additionally, the current meta-analysis includes more asymptomatic patients treated with aspirin for PAD and may represent a treatment effect by symptom status. The lack of clinical effectiveness of 100 mg daily of aspirin in addition to better (aggressive) management of cardiovascular risk factors is of clinical note and consistent with the meta-analysis by Berger et al. when viewed with regard to background therapy. The findings for clopidogrel monotherapy or DAPT were evaluated within subgroups of large RCTs.

Our finding that clopidogrel monotherapy is superior or equivalent to aspirin monotherapy in reducing adverse cardiovascular outcomes from one good-quality RCT in a PAD subgroup population represents current clinical practice and helps reinforce the current guideline recommendations for patients with PAD. The role for DAPT compared with aspirin monotherapy is less certain. From the PAD subgroup analysis of one large RCT 60 and a smaller study on a postrevascularization population,63 the combination of clopidogrel with aspirin as DAPT did not show a significant benefit in reducing stroke events or cardiovascular mortality in IC patients. In patients with symptomatic or asymptomatic PAD (92% IC, 8% asymptomatic), the PAD subgroup analysis of the CHARISMA study did however show a statistically significant benefit favoring dual therapy (clopidogrel plus aspirin) compared with aspirin for reducing nonfatal MI but showed no difference between aspirin and dual therapy for other outcomes. In the only other systematic review of antiplatelet agents for IC by the Cochrane group,137 the report included the results of the CAPRIE study, but did not contain the results of the CHARISMA or CASPAR studies. That review also included other antiplatelet agents such as indobufen, picotamide, ticlopidine, and triflusal, which are not prescribed in the United States. Recently, several new antiplatelet agents have been studied in patients with coronary artery disease, and the effects of these agents in patients with PAD is not known.

For KQ 2, our review found that exercise training improved functional measures for walking distance when indirectly compared with usual care or medical therapy. Endovascular therapy in our review was found to lead to a statistically nonsignificant functional improvement, although these studies again were limited by the multiple comparisons and possibility of bias. Patients treated with a combination of endovascular intervention and exercise training had better outcomes than patients treated with either exercise training or endovascular intervention alone in a study by Frans et al.138 These findings again highlight the need for more studies when viewed in context of the recent CLEVER RCT of exercise versus endovascular therapy for aortoiliac disease, which found greater functional improvement with exercise and greater quality-of-life improvement with endovascular therapy.77

Our findings for KQ 2 are consistent with existing systematic reviews of exercise therapy in patients with IC139,140 and with the systematic review for the NICE guidelines141 of medical therapy, supervised exercise, angioplasty, and surgical bypass for patients with IC. Current practice for patients with symptomatic PAD is to maximize medical and behavioral treatments prior to more invasive treatment with endovascular or surgical treatment. To examine the effectiveness of more invasive treatments, this review included any studies that assessed endovascular or surgical treatments versus usual care since 1995, which is when more effective medical treatments such as statins, ACE inhibitors, and adequate control of hypertension and diabetes were used as standard practice. Unfortunately, few surgical studies have been published since 1995. The endovascular studies in this review found mixed results on functional improvement except when combined with exercise training. The few studies that compared surgical treatment with usual care since 1995 provided little information on functional outcomes.

Our analysis also found evidence for improved walking function with medical therapy such as cilostazol, which is similar to a Cochrane review in 2008.^142^ In contrast to the few RCTs showing little functional effect over placebo with pentoxifylline leading to the Class IIB recommendation in the PAD guidelines, the current analysis incorporates RCTs and multiple comparison studies and shows a functional benefit of pentoxifylline, which is similar to the benefit seen in a meta-analysis by Girolami et al.143

The NICE guidelines focused on direct comparisons of specific therapies, and therefore the number of studies identified for each comparison was low and limited the authors' conclusions. In our systematic review, we used an effect size meta-analysis to assess the comparative effectiveness across all treatment strategies—medications, exercise training, endovascular interventions, and surgical revascularization—on the clinical outcomes outlined in KQ 2.

For KQ 3 in the CLI population, the current findings should serve as a call to action for further studies. This review found 1 RCT and 22 observational studies in the CLI population and 2 RCTs and 10 observational studies in a mixed IC-CLI population evaluating endovascular therapy versus surgical revascularization. The RCTs were performed in the balloon angioplasty-only era, and the observational studies suffer from risk of bias based on treatment decisions and patient inclusion. A Cochrane review of bypass surgery for CLI also concluded that there was limited evidence for the effectiveness of bypass surgery compared with angioplasty.144 The NICE evidence statements for the comparison of angioplasty and bypass surgery are primarily based on the only RCT conducted in the CLI population (i.e., the BASIL study). We understand that the subgroup analysis from the BASIL study found survival benefit of open bypass surgery for patients who survived longer than 2 years, but this subgroup analysis does not provide the level of evidence to make a key point and should instead be considered hypothesis-generating, rather than conclusive.145 Therefore, our findings the current variability and lack of a consistently agreed upon treatment approach for patients with CLI, as evidenced by the recommendations from current guidelines to perform revascularization based on best clinical judgment.

For assessing same-treatment strategy comparisons, the draft guidelines from NICE in March 2012^141^ and a previous AHRQ report on invasive interventions for lower extremity PAD in 2008^146^ contain meta-analyses regarding stent versus angioplasty, bare metal stent versus drug-eluting stent, angioplasty with selective stent placement versus angioplasty with primary stent placement, and autologous vein versus prosthetic bypass comparisons. The NICE report reviewed 10 RCTs comparing stent placement with angioplasty and found very low to low evidence of a difference in those modalities for any clinical outcomes, thus leading to the guideline recommendation to not offer primary stent placement for treating people with IC caused by aortoiliac disease (except complete occlusion) or femoropopliteal disease. The NICE report found one study (120 patients) that compared bare metal stents with drug-eluting stents, and the evidence was rated very low that vessel patency at 1 and 2 years was better with drug-eluting stents. Also there was no difference in clinical outcomes; therefore their recommendation was to use bare metal stents for IC. The AHRQ PAD report identified 10 RCTs and 11 observational studies evaluating stent versus PTA, primarily for femoropopliteal disease. Most RCTs used balloon-expandable stents, and two RCTs compared different stents. Overall, the RCTs and comparative observational studies failed to find a difference in the type of endovascular intervention for any clinical outcome. In addition, the studies were too heterogeneous to pool into a meta-analysis to estimate the relative differences in event rates. This review did not assess the comparative effectiveness of same-treatment strategies.

## Challenges in Evaluating the Existing Literature in PAD Patients

Comparing endovascular with surgical revascularization techniques in published studies has the following challenges:

1. Population differences: Inclusion and exclusion criteria have varied among studies, and stratification based on symptom status and procedural risk is important.
2. Endpoint differences: These differences include variable functional endpoints for evaluation of claudication therapies and the surgical literature that defines success by primary and secondary patency while the endovascular literature measures success by the lack of need for target lesion or target vessel revascularization.
3. Length of followup: Studies have been biased toward shorter duration of followup, thus heavily influencing differential ascertainment including the important clinical endpoint of amputation-free survival.
4. Evolution of revascularization techniques: Improvements in surgical and endovascular techniques have made direct comparisons between “state-of-the-art” strategies more challenging; we were unable to account for this in our analyses.
5. Crossover between surgical and endovascular therapies: Patients often undergo both surgical and endovascular revascularization in studies as well as in clinical practice, either as part of a hybrid approach to revascularization or because of treatment failure.

## Applicability

We used 1995 as the start date for the literature search to improve the applicability of the findings to current clinical practice where secondary prevention of cardiovascular events includes treatment of hypertension, diabetes, hyperlipidemia, and tobacco use. Current guideline recommendations include reaching specific blood pressure, hemoglobin A1c, and lipid-lowering goals as well as providing access to nicotine replacement therapy for smoking cessation. By removing studies prior to 1995, we acknowledge that earlier comparative studies of aspirin, dipyridamole, pentoxifylline, and surgical bypass were not included in this review. Including older studies with outdated background medical therapy for cardiovascular risk factors would have biased the results to favor active treatment over suboptimal usual care treatment.

The data available for antiplatelet agents in PAD treatment fell into two categories: (1) subgroup analysis of PAD patients in large antiplatelet RCTs and (2) smaller antiplatelet RCTs in patients who recently had an endovascular intervention or bypass surgery. There are no studies that specifically evaluate the role of antiplatelet agents in a population of patients representing the full spectrum of PAD (asymptomatic, IC, and CLI).

In the analysis of treatments for the IC population, there were a number of single-center and multicenter studies conducted outside the United States (primarily Europe). There were several RCTs comparing exercise training, medical therapies, and endovascular interventions. More of the studies comparing endovascular interventions with usual care or surgical revascularization were based on observational studies.

In the analysis of treatments for the CLI population, only one RCT of endovascular versus surgical revascularization has been conducted, with the majority of the literature based on observational, single-center studies. Subsequently, the introduction of stents, drug-eluting stents, and drug-coated balloons has likely changed the definition and results of the endovascular therapy group. Therefore, the available evidence for CLI revascularization is significantly limited with regard to applicability to current practice.

## Implications for Clinical and Policy Decisionmaking

PAD was identified by the Institute of Medicine as one of the top 100 priorities for comparative effectiveness research because of the large population of patients affected with significant morbidity and mortality, the multiple potential treatment options, and the high costs of care to the health care system. The current analysis provides an important evidence review that must be put in context with current clinical practice so that it may inform both future research and clinical and policy decisionmaking.

The findings for antiplatelet therapy demonstrate that monotherapy with clopidogrel 75 mg daily may be more effective than aspirin 100 mg daily for the prevention of cardiovascular events in the PAD population. The available evidence of aspirin monotherapy does not show a significant reduction in cardiovascular events compared with placebo. Additionally, from a large PAD subgroup of an RCT, clopidogrel and aspirin did not significantly reduce cardiovascular events compared with aspirin alone but did increase minor bleeding. These findings favor clopidogrel as the antiplatelet therapy for patients with PAD and, with introduction of the generic drug into clinical practice, may have important implications for health plans and medical systems. Finally, for studies aimed at improving the outcomes of patients with PAD, clopidogrel monotherapy seems justified as the current standard of care. It should be noted that the current AHA/ACC guidelines12 recommend an antiplatelet therapy with either aspirin or clopidogrel for patients with PAD based on both randomized data and some of the older observational studies.

Regarding the treatment of patients with IC, this review found that several therapies—exercise training, medical therapy, and endovascular therapy—were effective at improving functional status and walking time. However, these data are limited by many single-treatment comparisons, multiple functional endpoints, and the lack of rigorous strategy treatment studies where exercise and/or medical therapy are provided as background therapy. Since both the Centers for Medicare and Medicaid Services and most insurers do not currently cover supervised exercise for PAD, these types of studies and data are needed to build the evidence base regarding supervised exercise. Additionally, with increasing innovation of endovascular therapy, current well-performed multicenter RCTs and registry analysis of actual utilization are needed to determine efficacy.

Perhaps the largest and most important gap with implications for health policy and national funding may be seen in the evaluation of endovascular versus surgical therapy for CLI. Our analysis found one older RCT comparing balloon angioplasty to surgical bypass for patients with CLI, a condition that carries a significant morbidity and mortality. The remaining observational studies are at high risk for bias, have heterogeneous results, and highlight the need for further comparative effectiveness studies to determine the best current care for these patients. Such studies would need to enroll a broad population of patients with all available endovascular and surgical therapies.

## Limitations of the Review Process

The current review was limited to English-language–only studies and focused on those that compared two treatment modalities. This limited and excluded the single-arm studies examining endovascular or surgical therapy—most of which populate the current literature on PAD. Although some of these studies used objective performance criteria for comparison to existing or historical controls of practice, they were excluded for not having a direct comparison. However, it is unlikely these studies would have provided substantial additional information given the quality and SOE of the studies reviewed.

## Limitations of the Evidence Base

As we have noted, there are several limitations to the available evidence for the treatment of PAD. First and foremost, the majority of the available literature is single-arm observational studies without true direct comparisons with other treatment modalities or even with placebo. Additionally, when comparisons are made, many comparisons are within similar treatment modalities (i.e., endovascular therapy with stent A versus stent B, surgery with graft A versus graft B, or supervised versus structured home exercise). These comparisons may be meaningful; however, the current care pattern for patients with PAD demonstrates large variability. Several important treatment strategy studies are needed. Furthermore, the literature was insufficient to allow evaluation of the anatomic locations and severity of arterial disease that are often important in treatment decisionmaking. We found and reported subgroup findings from the small number of studies that did publish outcomes for these important patient factors. In addition, we were not able to assess the effectiveness of treatment strategies that were delivered if another modality had failed.

Regarding endpoints, there are numerous and heterogeneous measures reported, often with no clear agreed upon definition for patients with IC and CLI. The time points for followup are variable and often the ascertainment is not standardized. Finally, there are little data on important subgroups of harms.

## Research Gaps

The current literature search for PAD revealed many single-center, single-modality observational studies that could not be included for this comparative effectiveness review on the basis of our inclusion/exclusion criteria. In addition, there were many within-treatment comparisons; for example, studies comparing two types of surgical bypass, two types of endovascular interventions, or two types of exercise modalities. Studies that evaluated direct comparisons between treatments, unfortunately, were limited. From the ones we were able to identify, there was a notable variation in (1) outcome measures used to assess functional capacity and quality life, (2) followup assessment time points, and (3) type of outcomes reported (i.e., surrogate and hard clinical endpoints). Therefore, there are numerous areas of evidence gaps and areas for potential future research in PAD. We used the framework recommended by Robinson147 to identify gaps in the evidence and classify why these gaps exist using the PICOTS approach (Table 35). Gaps were classified as secondary to (1) insufficient or imprecise information, (2) biased information, (3) inconsistency or unknown consistency, and (4) not the right information.

Table 35 Research gaps

Criteria | Evidence Gap | Reason | Type of Studies To Consider
Patients | Comparative effectiveness of therapies for PAD subpopulations of interest, including subgroups based on: age, sex, race, risk factors, comorbidities and PAD classification (all KQs) | Insufficient information | RCTs and potentially patient-level meta-analyses of existing/future RCTs
Patients | Low representation of women and minorities (all KQs) | Insufficient information | RCTs and prospective registries with oversampling of female and minority populations
Interventions/comparators | Comparative effectiveness of new antiplatelet medications to aspirin or clopidogrel (KQ 1) | Insufficient information | RCTs
Interventions/comparators | Comparative effectiveness of DAPT to antiplatelet monotherapy (KQ 1) | Imprecise and inconsistent information | RCTs
Interventions/comparators | Comparative effectiveness of endovascular and surgical revascularization in CLI (KQ 3) | Imprecise and inconsistent information | RCTs
Outcomes | Comparative effectiveness of available therapies on functional capacity, quality of life in IC patients (KQ 2) | Imprecise and inconsistent information | RCTs or prospective cohort studies using standardized measures of patient-centered outcomes
Outcomes | Comparative effectiveness of available therapies on functional capacity, quality of life in CLI patients (KQ 3) | Insufficient information | RCTs or prospective cohort studies using standardized measures of patient-centered outcomes
Outcomes | Comparative effectiveness of available therapies on mortality (all-cause or cardiovascular), nonfatal MI, nonfatal stroke, and composite vascular events in the IC and CLI populations (KQ 2 and KQ 3) | Insufficient information | RCTs adequately powered to assess short- and long-term cardiovascular outcomes
Outcomes | Comparative effectiveness of available therapies in impacting healthcare utilitization (KQ 2 and KQ 3) | Insufficient information | Observational studies
Outcomes | Comparative safety of available therapies, focusing on harms such as such as bleeding, infection, and adverse drug reactions (KQ 2 and KQ 3, especially the exercise, endovascular, and surgical therapies) | Insufficient information | Reporting from RCTs and observational studies
Settings | Limited settings need larger real world populations represented (all KQs) | Insufficient information | Large, real-world registries

Abbreviations: CLI=critical limb ischemia; IC=intermittent claudication; RCTs=randomized controlled trials.

### KQ 1 Research Gaps

For KQ 1, the primary limitation of the available evidence was the low number of studies that compare the effectiveness of aspirin, clopidogrel, and new antiplatelet agents. A single RCT has compared clopidogrel with aspirin, and three RCTs have compared clopidogrel plus aspirin to aspirin alone. More RCTs on asymptomatic or symptomatic patients with PAD are needed to firmly conclude whether antiplatelet monotherapy or DAPT is warranted in this high-risk cardiovascular population. Most of the studies were also subgroup analyses of larger antiplatelet RCTs. Additionally, newer antiplatelet agents are available that have not been studied in the PAD population. RCTs that solely focus on enrollment of the PAD population are encouraged since much of the existing literature is based on PAD subgroups (often with an inclusion criteria for the main RCT of known coronary artery, cerebrovascular, or PAD).

### KQ 2 Research Gaps

For KQ 2, the primary limitation of the available evidence was the heterogeneity of outcome measures used to assess functional capacity in the IC population such that an effect size analysis had to be performed across the treatment strategies for this report. Some studies failed to report the variability of the mean, median, or percentage change result and so had to be excluded from the random-effects model. Also, the quality-of-life measures used varied among five instruments (SF-36, EQ-5D, WIQ, PAQ and VascuQOL). We focused on the results of the SF-36 physical functioning score since it was most commonly reported. Generic health-related quality-of-life measures, such as the SF-36 physical functioning score, are often thought to be less responsive to change than a disease-specific measure is. From the limited studies we analyzed, it appears that there was a large effect of various therapies on improving quality of life. Validation in future research using both general and disease-specific quality-of-life measures is encouraged, and treatment studies that evaluate exercise, medical therapy, and invasive approaches are needed.

### KQ 3 Research Gaps

For KQ 3, the primary limitation of the available evidence was the plethora of observational studies (only one RCT) comparing endovascular with surgical revascularization. A majority of these studies were rated poor quality due to insufficient reporting of study methodology and variability in the reporting of results. Since most of the studies were retrospective studies, there was a lack of assessment of functional capacity or quality-of-life measures. All-cause mortality and amputation (or limb salvage) rates were commonly reported. Newer studies have started to report amputation-free survival, but very few reported other vascular events such as MI or stroke, or minor amputations. The relationship between vessel patency and functional outcomes or quality of life is not well established, so this is viewed more as a surrogate clinical outcome and not a direct clinical outcome. More RCTs or prospective cohort studies with assessment of functional capacity, quality of life, and additional vascular outcomes are needed.

### Underreporting of Subgroup Results Across All KQs

Across all KQs, the underreporting of results for subgroups that may modify the comparative effectiveness was common. Given the limited space in publications, it would be helpful to have online, supplementary appendices that report the outcomes by age, race, sex, PAD classification, and comorbidities. The representation of women and the reporting of race/ethnicity were also low in these studies. Future studies that oversample for women and minority populations are needed to address subpopulation questions.

In addition, the reporting of safety concerns such as bleeding, exercise-related harms, infection, and adverse drug reactions was sparse in these studies. Underreporting may be expected in retrospective observational studies since medical documentation of safety issues are often lacking. However, we would expect that RCTs or prospective cohort studies would make this a priority to measure during the course of the study and to report in a published manuscript. Harms related to antiplatelet therapy (monotherapy or DAPT), endovascular procedures, and surgical interventions should be reported along with the treatment effectiveness results to determine the net benefit of therapies. Finally, although not a focus of this review, there was a lack of studies about health care utilization and costs associated with the various therapies. Observational studies using administrative datasets, or RCTs and prospective studies collecting and reporting resource use data are needed to address this evidence gap.

## Conclusions

The available evidence for treatment of patients with PAD is limited by few RCTs that provide comparisons of meaningful treatment options. Several advances in care in both medical therapy and invasive therapy have not been rigorously tested. With respect to antiplatelet therapy for the prevention of cardiovascular events in patients with PAD, we found from a limited number of studies that it appears that aspirin has no benefit over placebo in asymptomatic patients with PAD; clopidogrel monotherapy is more beneficial or equivalent to aspirin; and DAPT is not significantly better than aspirin on reducing cardiovascular events in patients with PAD. For IC patients, exercise, medical therapy, and endovascular or surgical revascularization all had an effect on improving functional status and quality of life; the impact of these therapies on cardiovascular events is uncertain. Additionally, the potential additive effects of these therapies are unknown. There does not appear to be significant differences in mortality or limb outcomes between endovascular and surgical revascularization in CLI patients. However, these data are derived from one RCT and many observational studies, and the presence of clinical heterogeneity of these results makes conclusions for clinical outcomes uncertain and provides an impetus for further research.