# Excluded Studies

All studies listed below were reviewed in their full-text version and excluded for the reason shown in bold. Reasons for exclusion signify only the usefulness of the articles for this study and are not intended as criticisms of the articles.

## Non-English language

Brosa M, Garcia-Cases C, Clerch L, et al. Cost-effectiveness analysis of cilostazol vs naftidrofuryl and pentoxifylline for the treatment of intermittent claudication in Spain. Angiologia. 2011;63(3):103-7.
Bulvas M, Chochola M, Herdova J, et al. Influence of heparan sulphate on the effect of percutaneous transluminal angioplasty in vessels supplying the lower extremities. Cas Lek Cesk. 1996;135(14):445-9. [pmid: 8925544].
Chikiar DS, Grandjean M, Abelleyra J. Femoropopliteal bypass grafting for arterial occlusive disease. Patency and complications. Randomized retrospective study. Prensa Med Argent. 2003;90(4):338-44.
Gloor B, Wehrli E, Rotzer A, et al. Polyurethane small artery substitutes for femoropopliteal above knee bypass. Clinical and angiomorphological follow up of 20 patients in a prospective, randomized trial. Swiss Surg. 1996;(Suppl 1):13-8.
Grenacher L, Saam T, Geier A, et al. PTA versus Palmaz stent placement in femoropopliteal artery stenoses: results of a multicenter prospective randomized study (REFSA). RoFo. 2004;176(9):1302-10. [pmid: 15346266].
Leo W, Westrych R, Bissinger A, et al. Effect of the acetylosalicyd acid (ASA) and ticlopidine therapy on clinical condition and parameters of blood platelets in patients with peripheral arterial occlusive disease (PAOD). Pol Merkuriusz Lek. 2007;23(137):335-9. [pmid: 18361314].
Marinel-Lo-Roura J, Alos-Vilacrosa J, Lopez-Palencia JA, et al. Endovascular surgery of the infrapopliteal segment. Angiologia. 2003;55(Suppl 1):S175-81.
Martin-Conejero A, Serrano-Hernando FJ, Rodriguez-Gonzalez R, et al. Treatment of occlusive pathologies of the superficial femoral artery with a Viabahn(registered trademark) device. Angiologia. 2008;60(2):117-25.
Matas-Docampo M, Royo-Serrando J, Dominguez-Gonzalez JM, et al. Endovascular surgery of the distal segment: The opposite position. Angiologia. 2003;55(Suppl 1):S182-9.
Mosimann UP, Stirnemann P. Chronic critical limb ischemia: The revascularization of the isolated popliteal segment compared to the femoro-distal bypass. Vasa. 1995;24(1):49-55. [pmid: 7725779].
Nasser F, Silva SGDJ, Biagioni RB, et al. Endovascular infrainguinal revascularization: Predictive factors for patency. J Vasc Bras. 2009;8(1):48-55.
Nicolai SPA, Prins MH, Teijink JaW. Supervised exercise therapy is more effective than walking advice in patients with intermittent claudication; a randomized multicenter study. Ned Tijdschr Geneeskd. 2011;155(2):55-62.
Ortigosa Mateo AB, Gutierrez Julian JM, Rivas Dominguez M, et al. Clinical results of femoropopliteal endovascular treatment in patients with critical limb ischaemia. Angiologia. 2010;62(3):103-9.
Panella-Agusti F, Berga-Fauria C, Hernandez-Osma E, et al. Iliofemoral or femorofemoral by-pass. Which is the best option? A long-term follow-up study. Angiologia. 2003;55(6):526-33.
Plaza-Martinez A, Riera-Vazquez R, Diaz-Lopez M, et al. Value of endovascular treatment in the iliac sector. Angiologia. 2002;54(4):282-90.
Ramirez Saavedra OA. Sequential distal bypass: A resolved surgery in diabetic foot with TASC D gangrene and lesions. Rev Mex Angiol. 2010;38(2):46-50.
Rognoni A, Zelaschi F, Felicetti G, et al. Rehabilitation of the peripheral arterial obstructive disease: Efficacy of aerobic training. Eur Medicophys. 1995;31(4):207-13.
Schlenger R. Cilostazol therapy improves the ability to walk in patients with peripheral occlusive artery disease. Dtsch Apoth Ztg. 2007;147(10):34-6.
Stierli P, Eugster T, Hess P, et al. Occlusion of the superficial femoral artery. Choice of material for a bypass to the above-knee popliteal artery. Gefasschirurgie. 2001;6(Suppl 1):S43-6.
Tan JY, Shi WH, He J, et al. A clinical trial of using antiplatelet therapy to prevent restenosis following peripheral artery angioplasty and stenting. Nat Med J China. 2008;88(12):812-5. [pmid: 18756983].
Tetteroo E, Van Der Graaf Y, Van Engelen AD, et al. No difference in effect on intermittent claudication between primary stent placement and primary percutaneous transluminal angio plasty followed by selective stent placement: A prospective randomized trial. Ned Tijdschr Geneeskd. 2000;144:167-71.
Trejo JMR, Sanchez IE, Ramirez NR, et al. Surgery for the rescue of critical limb ischemia. Rev Mex Angiol. 2008;36(3):88-97.
Utrilla-Fernandez F, Acin-Garcia F, March-Garcia JR, et al. Angioplasty versus angioplasty plus stent-graft in the infrainguinal segment. Results of 100 consecutive endovascular procedures. Angiologia. 2004;56(4):367-79.
Van Der Zaag ES, Prins MH, Jacobs MJ. Treatment of intermittent claudication; prospective randomized study in the BAESIC-Trial (bypass, angioplasty or endarterectomy patients with severe intermittent claudication). Ned Tijdschr Geneeskd. 1996;140(14):787-8. [pmid: 8668267].
Zhu BP, Fan L, Li XY. Long-term effect and reliability of warfarin and aspirin for primary prevention of cardio-cerebral vessels events in patients with peripheral arteriosclerotic occlusive disease: a randomized, single-blind, controlled clinical trial with two-year follow-up. Chin J Clin Rehab. 2005;9(15):10-1.
Zimmermann A, Berger H, Eckstein HH. The ABC (angioplasty or bypass surgery in intermittent claudication) trial: Background and study design. Gefasschirurgie. 2010;15(1):5-10.

## Not a full publication (abstract only), not original data, not peer-reviewed literature published 1995 to present, not a clinical study (e.g., editorial, non-systematic review, letter to the editor, case series), animal study

Ahanchi SS, Chen B, Steerman S, et al. The use of reentry devices improves the technical success, safety, and patency of recanalization of chronic total occlusions of the iliac arteries. J Vasc Surg. 2012;55(6 Suppl 1):88S-89S.
Anonymous. Meta-analysis of antiplatelet trials. Pharm J. 2002;268(7180):7.
Anonymous. Stenting for peripheral artery disease of the lower extremities: An evidence-based analysis. Ont Health Technol Assess Ser. 2010;10(18):1-88. [pmid: 23074395].
Atsushi T, Soga Y, Iida O, et al. Predictors of early mortality in patients with critical limb ischemia caused by isolated below-the-knee artery disease. J Am Coll Cardiol. 2012;59(13Suppl 1):E2109.
Beebe HG, Dawson DL, Cutler BS, et al. Cilostazol, a new treatment for intermittent claudication: results of a randomized, multicenter trial. Circulation. 1997;96(8):66.
Belch J, Maccuish A, Campbell I. No benefit of daily low-dose aspirin in diabetic patients with peripheral arterial disease. J Clin Outcomes Manage. 2008;15(12):575-6.
Belkin M, Donaldson MC, Whittemore AD. Composite autogenous vein grafts. Semin Vasc Surg. 1995;8(3):202-8. [pmid: 8564033].
Bell J, Papp L, Bradbury AW. Bypass or angioplasty for sever ischaemia of the leg: the BASIL trial. Vascular and endovascular opportunities. 2000:485-94.
Bosch JL, Tetteroo E, Mali WP, et al. Iliac arterial occlusive disease: cost-effectiveness analysis of stent placement versus percutaneous transluminal angioplasty. Dutch Iliac Stent Trial Study Group. Radiology. 1998;208(3):641-8. [pmid: 9722840].
Bradbury AW, Adam DJ, Bell J, et al. Erratum: Bypass versus Angioplasty in Severe Ischaemia of the Leg (BASIL) Trial: a description of the severity and extent of disease using the Bollinger angiogram scoring method and the TransAtlantic Inter-Society Consensus II classification. (J Vasc Surg. 2010;51( Suppl.5):32S-42S). J Vasc Surg. 2010;(6):1751.
Bradbury AW, Adam DJ, Bell J, et al. Erratum: Bypass versus Angioplasty in Severe Ischaemia of the Leg (BASIL) Trial: a survival prediction model to facilitate clinical decision making. (J Vasc Surg. 2010;51(Suppl.5):52S-68S). J Vasc Surg. 2010;(6):1751.
Bradbury AW, Adam DJ, Bell J, et al. Erratum: Bypass versus Angioplasty in Severe Ischaemia of the Leg (BASIL) Trial: an intention-to-treat analysis of amputation-free and overall survival in patients randomized to a bypass surgery-first or a balloon angioplasty-first revascularization strategy. (J Vasc Surg. 2010;51(Suppl.5):5S-17S). J Vasc Surg. 2010;(6):1751.
Bradbury AW, Adam DJ, Bell J, et al. Erratum: Bypass versus Angioplasty in Severe Ischaemia of the Leg (BASIL) Trial: analysis of amputation free and overall survival by treatment received. (J Vasc Surg. 2010;51(Suppl.5):18S-31S). J Vasc Surg. 2010;(6):1751.
Breek JC, De Vries J, Hamming JF. The Oslo Balloon Angioplasty versus Conservative Treatment Study (OBACT) - The 2-years results of a single centre, prospective, randomised study in patients with intermittent claudication. Eur J Vasc Endovasc Surg. 2007;34(3):378. [pmid: 17582794].
Caro JJ, Migliaccio-Walle K. Generalizing the results of clinical trials to actual practice: the example of clopidogrel therapy for the prevention of vascular events. CAPRA (CAPRIE Actual Practice Rates Analysis) Study Group. Clopidogrel versus Aspirin in Patients at Risk of Ischaemic Events. Am J Med. 1999;107(6):568-72. [pmid: 10625025].
Cassar K, Bachoo P, Ford I, et al. Variability in responsiveness to clopidogrel in patients with intermittent claudication. The Vascular Society of Great Britain & Ireland Yearbook. 2005. 2005;Abstract no: 66.
Cassar K, Ford I, Greaves M, et al. The CAVA study: a double-blind randomized controlled trial of clopidogrel and aspirin vs. aspirin alone in patients with intermittent claudication undergoing peripheral percutaneous transluminal angioplasty. J Thromb Haemost. 2003;(Suppl 1). Abstract no: P2009.
Cejna M, Durakovic N, Mathies R, et al. Long-term follow-up and total cost analysis of in-hospital invasive interdisciplinary treatment of critical limb ischemia: Comparison of surgical and endovascular therapy. CardioVascular and Interventional Radiology. 2011;34(Suppl 3):528.
Clement Darling R, Mehta M, Roddy SP, et al. Distal bypass in the endovascular-first era: Is there still a need for open surgery?. J Vasc Surg. 2011;54(3):922-3.
Cull DL, Langan EM, Gray BH, et al. Open versus endovascular intervention for critical limb ischemia: a population-based study. J Am Coll Surg. 2010;210(5):555-61. 561. 3. [pmid: 20421003].
Dardik H. Regarding “a comparative evaluation of polytetrafluoroethylene, umbilical vein, and saphenous vein bypass grafts for femoral-popliteal above-knee revascularization: a prospective randomized Department of Veterans Affairs cooperative study”. J Vasc Surg. 2001;33(3):658-9. [pmid: 11241144].
Dawson DL, Beebe HG, Herd JA, et al. Cilostazol or pentoxifylline for claudication. Circulation. 1998;(Suppl 1):12. [pmid: 9443424].
Drozdz W, Lejman W. Response to exercise training in patients with intermittent claudication. Pol Prz Chir. 2006;78(1):85-105.
Farkouh ME. 2008-- aspirin and/or antioxidants did not prevent CV events in diabetes and peripheral arterial disease. ACP Journal Club. 2009;150:JC1-8.
Flis V, Pavlovic M, Miksic K. The value of adjunctive vein patches to improve the outcome of femorodistal polytetrafluoroethylene bypass grafts. Wien Klin Wochenschr. 2001;113(Suppl.3):5-10. [pmid: 15503612].
Friedberg MW. Supervised exercise is equivalent to endovascular revascularization for the treatment of intermittent claudication. J Clin Outcomes Manage. 2009;16(8):349-50.
Gaines P. Results of bypass vs. interventional radiology for occlusive disease. Cardiovasc Intervent Radiol. 2011;34(Suppl.3):336-8.
Gardner AW, Montgomery PS, Parker DE. Optimal exercise program length for patients with claudication: A randomized controlled trial. J Cardiopulm Rehabil Prev. 2011;31(4):E4-5.
Gardner AW. Supervised exercise therapy provided by local physiotherapists improves walking distance in patients with claudication. Evid-Based Med. 2011;16(2):43-4. [pmid: 21427053].
Greenhalgh J, Bagust A, Boland A, et al. Clopidogrel and modified-release dipyridamole for the prevention of occlusive vascular events (review of Technology Appraisal No. 90): a systematic review and economic analysis. Health Technol Assess. 2011;15(31):1-178. [pmid: 21888837].
Grenon SM, Conte MS. Aspirin prophylaxis (100 mg daily) does not improve cardiovascular outcomes compared to placebo in asymptomatic individuals with incidental low-ankle brachial index. Evid-Based Med. 2010;15(4):106-8. [pmid: 20530607].
Guest JF, Davie AM, Clegg JP. Cost effectiveness of cilostazol compared with naftidrofuryl and pentoxifylline in the treatment of intermittent claudication in the UK. Curr Med Res Opin. 2005;21(6):817-26. [pmid: 15969881].
Hamburg NM, Balady GJ. Exercise rehabilitation in peripheral artery disease: functional impact and mechanisms of benefits. Circulation. 2011;123(1):87-97. [pmid: 21200015].
Harker LA, Boissel JP, Pilgrim AJ, et al. Comparative safety and tolerability of clopidogrel and aspirin: results from CAPRIE. CAPRIE Steering Committee and Investigators. Clopidogrel versus aspirin in patients at risk of ischaemic events. Drug Saf. 1999;21(4):325-35. [pmid: 10514023].
Hepp W, Von Bary S, Corovic D, et al. Intravenous prostaglandin E1 versus pentoxifylline: a randomized controlled study in patients with intermittent claudication. Int Angiol. 1995;(Suppl 1):280.
Hiatt WR, Cooper LT, Morgan RE, et al. Clinical effects of the phosphodiesterase inhibitor K-134 in peripheral artery disease and claudication. Circulation. 2011;124(21):A9800.
Hong JB, Jeon YS, Cho SG, et al. Endovascular treatment as a reasonable option for extensive total occlusion of iliac artery. Am J Cardiol. 2012;109(7):138S-139S.
Huber TS. Commentary. Anand, Yusuf, Xie, et al. The Warfarin Antiplatelet Vascular Evaluation Trial Investigators. Oral anticoagulation and antiplatelet therapy and peripheral arterial disease. N Engl J Med. 2007;357:217-227. Perspect Vasc Surg Endovasc Ther. 2008;20(4):383-4. [pmid: 19095638].
Hunink MG, Wong JB, Donaldson MC, et al. Revascularization for femoropopliteal disease. A decision and cost-effectiveness analysis. JAMA. 1995;274(2):165-71. [pmid: 7596006].
Jacomella V, Shenoy A, Mosimann K, et al. Impact of lower limb revascularization on aortic augmentation index and subendocardial viability ratio in patients with peripheral arterial disease. Atheroscler Suppl. 2011;12(1):70.
Kalani M, Apelqvist J, Blomback M, et al. Dalteparin improved chronic foot ulcers and reduced the number of amputations in diabetic peripheral arterial occlusive disease. Evid-Based Med. 2004;9(3):73.
Karnon J, Brennan A, Pandor A, et al. Modelling the long term cost effectiveness of clopidogrel for the secondary prevention of occlusive vascular events in the UK. Curr Med Res Opin. 2005;21(1):101-12. [pmid: 15881481].
Killewich LA. Improving functional status and quality of life in elderly patients with peripheral arterial disease. J Am Coll Surg. 2006;202(2):345-55. [pmid: 16427563].
Kruidenier LM, Nicola SP. Additional supervised exercise therapy after a percutaneous vascular intervention for peripheral arterial disease: A randomized clinical trial. J Vasc Surg. 2011;54(6):1846.
Lee HL, Mehta T, Ray B, et al. A trial of the clinical and cost-effectiveness of a supervised exercise programme for claudication. Br J Surg. 2005;92(Suppl 1):11.
Masser PA, Taylor LM Jr, Moneta GL, et al. Technique of reversed vein bypass for lower extremity ischemia. Ann Vasc Surg. 1996;10(2):190-200. [pmid: 8733873].
Mazari F, Khan J, Abdul Rahman MNA, et al. Cost utility analysis of a randomised control trial of percutaneous transluminal angioplasty (PTA), supervised exercise programme (SEP) and combined treatment (PTA+SEP) for patients with intermittent claudication (IC) due to femoropopliteal disease. The Vascular Society of Great Britain & Ireland Yearbook. 2009;2009:44.
Mehta M, Ramay F, Roddy SP, et al. Cost per day of patency: Long-term implications of patency and reinterventions after endovascular vs surgical lower extremity revascularizations. J Vasc Surg. 2011;54(4):1227-8.
Melton C. Supervised exercise program helps patients with peripheral artery disease walk longer. Clin Geriatr. 2011;19(12):17.
Mewissen MW. IX.4 direct stenting in long femoropopliteal lesions. Vascular. 2005;13(Suppl 1):S47-9.
Mohler ER 3rd, Beebe HG, Salles-Cuhna S, et al. Effects of cilostazol on resting ankle pressures and exercise-induced ischemia in patients with intermittent claudication. Vasc Med. 2001;6(3):151-6. [pmid: 11789969].
Murphy TP. Supervised exercise vs. primary stenting for claudication due to aorto-iliac peripheral artery disease: 6-month outcomes from the CLEVER Study. Eur Heart J. 2012;33(1):144-5.
Nair V, Chaisson G, Abben R. Strategies in infrapopliteal intervention: improving outcomes in challenging patients. J Interv Cardiol. 2009;22(1):27-36. [pmid: 19281520].
Nordanstig J, Gelin J, Hensater M, et al. Walking performance and health-related quality of life after surgical or endovascular invasive versus non-invasive treatment for intermittent claudication - A prospective randomised trial. J Vasc Surg. 2011;54(2):584.
Pande RL, Hiatt WR, Zhang P, et al. A pooled analysis of the durability and predictors of treatment response of cilostazol in patients with intermittent claudication. Vasc Med. 2010;15(3):181-8. [pmid: 20385711].
Patel MR, Becker RC, Wojdyla DM, et al. Cardiovascular events in acute coronary syndrome patients with peripheral arterial disease treated with ticagrelor compared to clopidogrel: Data from the PLATO trial. Circulation. 2011;124(24):A14299.
Price JF, Leng GC, Fowkes FG. Should claudicants receive angioplasty or exercise training?. Cardiovasc Surg. 1997;5(5):463-70. [pmid: 9464601].
Renwick P, Johnson B, Wilkinson A, et al. Vascular surgical society of great britain and ireland: limb outcome following failed femoropopliteal polytetrafluoroethylene bypass for intermittent claudication. Br J Surg. 1999;86(5):693. [pmid: 10361318].
Roitman JL. Treadmill exercise and resistance training in patients with peripheral arterial disease with and without in intermittent claudication: A randomized controlled trial. J Cardiopulm Rehabil Prev. 2010;30(1):62.
Shindelman LE. Experience with the LuMend Frontrunner CTO Catheter System for the Treatment of TASC D SFA Lesions. J Invasive Cadiol. 2004;16(Suppl B):13.
Shiraki T, Iida O, Fujita M, et al. Predictors of mortality within 2-year after endovascular therapy for patients with critical limb ischemia. J Am Coll Cardiol. 2012;59(13Suppl 1):E2103.
Singer E, Imfeld S, Hoffmann U, et al. Aspirin in peripheral arterial disease: breakthrough or pitfall?. Vasa. 2006;35(3):174-7. [pmid: 16941406].
Soejima H, Morimoto T, Saito Y, et al. Aspirin for the primary prevention of cardiovascular events in patients with peripheral artery disease or diabetes mellitus. Analyses from the JPAD, POPADAD and AAA trials. Thromb Haemost. 2010;104(6):1085-8. [pmid: 20941462].
Sood J. Is the antiplatelet effect of aspirin sufficient in atherosclerosis?. Pharm Pract. 2008;18(4):133-5.
Strandness DE, Dalman R, Panian S, et al. Two doses of Cilostazol versus placebo in the treatment of claudication: results of a randomized, multicenter trial. Circulation. 1998;17(Suppl 1):12.
Strobl F, Bantleon R, Schmehl J, et al. Management of peripheral arterial interventions with mono or dual antiplatelet therapy. MIRROR study. Eur Heart J. 2011;32(Suppl 1):1053.
Sultan S, Tawfick W. Technical superiority and clinical excellence of duplex ultrsound arterial maping (DUAM) versus magnetic resonance angiogram (MRA) as the sole imaging modality in bypass surgery (BS) and endovascular revascularization (EVR) for critical lower ischemia (CLI) patients: A six-year comparative study in a tertiary referral vascular centre. J Vasc Surg. 2012;55(6 Suppl 1):71S.
Thomason AR, Skipwith DF. Lower extremity peripheral arterial disease. US Pharm. 2007;32(2).
Thomson IA, Van Rij AM, Morrison ND, et al. A ten year randomised controlled trial of percutaneous femoropopliteal angioplasty for claudication. ANZ J Surg. 1999;69(Suppl):98.
Tovar-Pardo AE, Bernhard VM. Where the profunda femoris artery fits in the spectrum of lower limb revascularization. Semin Vasc Surg. 1995;8(3):225-35. [pmid: 8564036].
Tran H. Vascular viewpoint. Vasc Med. 2004;9(1):90. [pmid: 15495365].
Walsh SR, Tang TY, Cooper DG, et al. Remote ischemic preconditioning will reduce graft-related events after surgical infrainguinal revascularization: evidence-based surgery hypothesis. Surgery. 2010;148(5):1020-1. [pmid: 20472262].
Weismantel D. Is cilostazol more effective than pentoxifylline in the treatment of symptoms of intermittent claudication?. J Fam Pract. 2001;50(2):181. [pmid: 11219570].
Whyman MR, Fowkes FGR, Kerracher EMG, et al. Intermittent claudication is not improved by percutaneous transluminal angioplasty - A randomised controlled trial. BJS. 1996;35.

## Does not include a study population of interest

Bhatt DL, Hirsch AT, Ringleb PA, et al. Reduction in the need for hospitalization for recurrent ischemic events and bleeding with clopidogrel instead of aspirin. CAPRIE investigators. Am Heart J. 2000;140(1):67-73. [pmid: 10874265].
Butterfield JS, Fitzgerald JB, Razzaq R, et al. Early mobilization following angioplasty. Clin Radiol. 2000;55(11):874-7. [pmid: 11069744].
Campeau L, Lesperance J, Bilodeau L, et al. Effect of cholesterol lowering and cardiovascular risk factors on the progression of aortoiliac arteriosclerosis: a quantitative cineangiography study. Angiology. 2005;56(2):191-9. [pmid: 15793608].
Carroccio A, Faries PL, Morrissey NJ, et al. Predicting iliac limb occlusions after bifurcated aortic stent grafting: anatomic and device-related causes. J Vasc Surg. 2002;36(4):679-84. [pmid: 12368725].
Drozdz W, Wilczek M, Gajdzinska K, et al. Mechanisms of symptomatic relief observed after conservative treatment or revascularization in patients with chronic lower limb ischemia. Pol Prz Chir. 2004;76(4):359-72.
Eikelboom JW, Hankey GJ, Thom J, et al. Incomplete inhibition of thromboxane biosynthesis by acetylsalicylic acid: determinants and effect on cardiovascular risk. Circulation. 2008;118(17):1705-12. [pmid: 18838564].
Gschwandtner ME, Minar E, Ahmadi A, et al. Impact of different therapeutic alternatives in treatment of severe limb ischemia: experiences on 190 consecutive patients at a department of medical angiology. Vasa. 1999;28(4):271-8. [pmid: 10611845].
Harker LA, Boissel JP, Pilgrim AJ, et al. Comparative safety and tolerability of clopidogrel and aspirin: results from CAPRIE. CAPRIE Steering Committee and Investigators. Clopidogrel versus aspirin in patients at risk of ischaemic events. Drug Saf. 1999;21(4):325-35. [pmid: 10514023].
Julliard W, Katzen J, Nabozny M, et al. Long-term results of endoscopic versus open saphenous vein harvest for lower extremity bypass. Ann Vasc Surg. 2011;25(1):101-7. [pmid: 21172585].
Kreienberg PB, Darling RC 3rd, Chang BB, et al. Adjunctive techniques to improve patency of distal prosthetic bypass grafts: polytetrafluoroethylene with remote arteriovenous fistulae versus vein cuffs. J Vasc Surg. 2000;31(4):696-701. [pmid: 10753277].
Lee ES, Steenson CC, Trimble KE, et al. Comparing patency rates between external iliac and common iliac artery stents. J Vasc Surg. 2000;31(5):889-94. [pmid: 10805878].
Leizorovicz A, Becker F. Oral buflomedil in the prevention of cardiovascular events in patients with peripheral arterial obstructive disease: a randomized, placebo-controlled, 4-year study. Circulation. 2008;117(6):816-22. [pmid: 18212283].
Lepantalo M, Salenius JP, Alback A, et al. Frequency of repeated vascular surgery. A survey of 7616 surgical and endovascular Finnvasc procedures. Finnvasc Study Group. Eur J Surg. 1996;162(4):279-85. [pmid: 8739414].
Lombardini R, Marchesi S, Collebrusco L, et al. The use of osteopathic manipulative treatment as adjuvant therapy in patients with peripheral arterial disease. Man Ther. 2009;14(4):439-43. [pmid: 18824395].
Lopez-Galarza LA, Ray LI, Rodriguez-Lopez J, et al. Combined percutaneous transluminal angioplasty, iliac stent deployment, and femorofemoral bypass for bilateral aortoiliac occlusive disease. J Am Coll Surg. 1997;184(3):249-58. [pmid: 9060920].
Louridas G, Saadia R, Spelay J, et al. The ArtAssist Device in chronic lower limb ischemia. A pilot study. Int Angiol. 2002;21(1):28-35. [pmid: 11941271].
Mak KH, Bhatt DL, Shao M, et al. The influence of body mass index on mortality and bleeding among patients with or at high-risk of atherothrombotic disease. Eur Heart J. 2009;30(7):857-65. [pmid: 19233855].
Milio G, Coppola G, Novo S. The effects of prostaglandin E-1 in patients with intermittent claudication. Cardiovasc Hematol Disord Drug Targets. 2006;6(2):71-6. [pmid: 16787192].
Mukherjee D, Topol EJ, Moliterno DJ, et al. Extracardiac vascular disease and effectiveness of sustained clopidogrel treatment. Heart. 2006;92(1):49-51. [pmid: 15845611].
Newton W. Does aspirin heal leg ulcers?. J Fam Pract. 1995;40(1):93. [pmid: 7807046].
Nguyen LL, Lipsitz SR, Bandyk DF, et al. Resource utilization in the treatment of critical limb ischemia: The effect of tissue loss, comorbidities, and graft-related events. J Vasc Surg. 2006;44(5):971-5. discussion 975-6. [pmid: 17098527].
Oka RK, Szuba A, Giacomini JC, et al. A pilot study of L-arginine supplementation on functional capacity in peripheral arterial disease. Vasc Med. 2005;10(4):265-74. [pmid: 16444855].
Pomposelli FB Jr, Marcaccio EJ, Gibbons GW, et al. Dorsalis pedis arterial bypass: durable limb salvage for foot ischemia in patients with diabetes mellitus. J Vasc Surg. 1995;21(3):375-84. [pmid: 7877219].
Presern-Strukelj M, Poredos P. The influence of electrostimulation on the circulation of the remaining leg in patients with one-sided amputation. Angiology. 2002;53(3):329-35. [pmid: 12025921].
Proia RR, Walsh DB, Nelson PR, et al. Early results of infragenicular revascularization based solely on duplex arteriography. J Vasc Surg. 2001;33(6):1165-70. [pmid: 11389413].
Robbs JV, Paruk N. Management of HIV vasculopathy - a South African experience. Eur J Vasc Endovasc Surg. 2010;39(Suppl 1):S25-31. [pmid: 20189418].
Rodgers A, Macmahon S. Antiplatelet therapy and the prevention of thrombosis. Aust N Z J Med. 1996;26(2):210-5. [pmid: 8744620].
Rustempasic N, Solakovic E, Rustempasic M, et al. Evaluation of medical and surgical management of critical extremity ischemia caused by atherothrombosis. Med Arh. 2010;64(6):328-31. [pmid: 21218748].
Samson RH, Showalter DP, Yunis JP. Isolated femoropopliteal bypass graft for limb salvage after failed tibial reconstruction: a viable alternative to amputation. J Vasc Surg. 1999;29(3):409-12. [pmid: 10069904].
Schleinitz MD, Weiss JP, Owens DK. Clopidogrel versus aspirin for secondary prophylaxis of vascular events: a cost-effectiveness analysis. Am J Med. 2004;116(12):797-806. [pmid: 15178495].
Shukla V. Cilostazol: a replacement for pentoxifylline?. Issues Emerg Health Technol. 1999;(7):1-4. [pmid: 11811214].
Steinhubl SR, Bhatt DL, Brennan DM, et al. Aspirin to prevent cardiovascular disease: the association of aspirin dose and clopidogrel with thrombosis and bleeding. Ann Intern Med. 2009;150(6):379-86. [pmid: 19293071].
Toursarkissian B, Shireman PK, Schoolfield J, et al. Outcomes following distal bypass graft occlusion in diabetics. Ann Vasc Surg. 2003;17(6):670-5. [pmid: 14534843].
Vikram R, Ross RA, Bhat R, et al. Cutting balloon angioplasty versus standard balloon angioplasty for failing infra-inguinal vein grafts: comparative study of short- and mid-term primary patency rates. Cardiovasc Intervent Radiol. 2007;30(4):607-10. [pmid: 17393055].
Visser K, De Vries SO, Kitslaar PJ, et al. Cost-effectiveness of diagnostic imaging work-up and treatment for patients with intermittent claudication in The Netherlands. Eur J Vasc Endovasc Surg. 2003;25(3):213-23. [pmid: 12623332].
Yamasaki Y, Kim YS, Kawamori R. Rationale and protocol of a trial for prevention of diabetic atherosclerosis by using antiplatelet drugs: Study of Diabetic Atherosclerosis Prevention by Cilostazol (DAPC study). Cardiovasc Diabetol. 2006;5:16. [pmid: 16925808].
Yeomans ND, Lanas AI, Talley NJ, et al. Prevalence and incidence of gastroduodenal ulcers during treatment with vascular protective doses of aspirin. Aliment Pharmacol Ther. 2005;22(9):795-801. [pmid: 16225488].

## Does not include intervention/comparators of interest

Allie DE, Hebert CJ, Lirtzman MD, et al. A safety and feasibility report of combined direct thrombin and GP IIb/IIIa inhibition with bivalirudin and tirofiban in peripheral vascular disease intervention: treating critical limb ischemia like acute coronary syndrome. J Invasive Cardiol. 2005;17(8):427-32. [pmid: 16079449].
Allie DE, Hebert CJ, Lirtzman MD, et al. Combined glycoprotein IIb/IIIa and direct thrombin inhibition with eptifibatide and bivalirudin in the interventional treatment of critical limb ischemia: A safety and feasibility report. Vasc Dis Manage. 2006;3(6):368-75.
Anand S, Yusuf S, Xie C, et al. Oral anticoagulant and antiplatelet therapy and peripheral arterial disease. N Engl J Med. 2007;357(3):217-27. [pmid: 17634457].
Antonicelli R, Sardina M, Scotti A, et al. Randomized trial of the effects of low-dose calcium-heparin in patients with peripheral arterial disease and claudication. Italian CAP Study Group. Am J Med. 1999;107(3):234-9. [pmid: 10492316].
Aune S, Laxdal E. Above-knee prosthetic femoropopliteal bypass for intermittent claudication. Results of the initial and secondary procedures. Eur J Vasc Endovasc Surg. 2000;19(5):476-80. [pmid: 10828227].
Awad S, Karkos CD, Serrachino-Inglott F, et al. The impact of diabetes on current revascularisation practice and clinical outcome in patients with critical lower limb ischaemia. Eur J Vasc Endovasc Surg. 2006;32(1):51-9. [pmid: 16488631].
Badger SA, Soong CV, O'donnell ME, et al. Benefits of a supervised exercise program after lower limb bypass surgery. Vasc Endovascular Surg. 2007;41(1):27-32. [pmid: 17277240].
Baldwin ZK, Pearce BJ, Curi MA, et al. Limb salvage after infrainguinal bypass graft failure. J Vasc Surg. 2004;39(5):951-7. [pmid: 15111843].
Berceli SA, Hevelone ND, Lipsitz SR, et al. Surgical and endovascular revision of infrainguinal vein bypass grafts: analysis of midterm outcomes from the PREVENT III trial. J Vasc Surg. 2007;46(6):1173-9. [pmid: 17950564].
Bregar U, Poredos P, Sabovic M, et al. The influence of atorvastatin on walking performance in peripheral arterial disease. Vasa. 2009;38(2):155-9. [pmid: 19588303].
Cachovan M, Rogatti W, Creutzig A, et al. Treadmill testing for evaluation of claudication: comparison of constant-load and graded-exercise tests. Eur J Vasc Endovasc Surg. 1997;14(4):238-43. [pmid: 9366786].
Cachovan M, Rogatti W, Woltering F, et al. Randomized reliability study evaluating constant-load and graded-exercise treadmill test for intermittent claudication. Angiology. 1999;50(3):193-200. [pmid: 10088798].
Carreira JM, Reyes R, Gude F, et al. Long-term follow-up of Symphony nitinol stents in iliac arteriosclerosis obliterans. Minim Invasive Ther Allied Technol. 2008;17(1):34-42. [pmid: 18270875].
Chaudhry H, Holland A, Dormandy J. Comparison of graded versus constant treadmill test protocols for quantifying intermittent claudication. Vasc Med. 1997;2(2):93-7. [pmid: 9546962].
Delis KT, Nicolaides AN, Wolfe JH, et al. Improving walking ability and ankle brachial pressure indices in symptomatic peripheral vascular disease with intermittent pneumatic foot compression: a prospective controlled study with one-year follow-up. J Vasc Surg. 2000;31(4):650-61. [pmid: 10753272].
Djoric P. Early individual experience with distal venous arterialization as a lower limb salvage procedure. Am Surg. 2011;77(6):726-30. [pmid: 21679641].
Donas KP, Schwindt A, Pitoulias GA, et al. Endovascular treatment of internal iliac artery obstructive disease. J Vasc Surg. 2009;49(6):1447-51. [pmid: 19497505].
Dosluoglu HH, Attuwaybi B, Cherr GS, et al. The management of ischemic heel ulcers and gangrene in the endovascular era. Am J Surg. 2007;194(5):600-5. [pmid: 17936420].
Dosluoglu HH, Cherr GS, Lall P, et al. Peroneal artery-only runoff following endovascular revascularizations is effective for limb salvage in patients with tissue loss. J Vasc Surg. 2008;48(1):137-43. [pmid: 18502081].
Duschek N, Vafaie M, Skrinjar E, et al. Comparison of enoxaparin and unfractionated heparin in endovascular interventions for the treatment of peripheral arterial occlusive disease: A randomized controlled trial. J Thromb Haemost. 2011;9(11):2159-67. [pmid: 21910821].
Engelhardt M, Boos J, Bruijnen H, et al. Critical limb ischaemia: Initial treatment and predictors of amputation-free survival. Eur J Vasc Endovasc Surg. 2012;43(1):55-61. [pmid: 22001150].
Esperon A, Kamaid E, Diamant M, et al. Uruguayan experience with cryopreserved arterial homografts. Transplant Proc. 2009;41(8):3500-4. [pmid: 19857780].
Fernandez N, Mcenaney R, Marone LK, et al. Multilevel versus isolated endovascular tibial interventions for critical limb ischemia. J Vasc Surg. 2011;54(3):722-9. [pmid: 21803523].
Fiotti N, Altamura N, Cappelli C, et al. Long term prognosis in patients with peripheral arterial disease treated with antiplatelet agents. Eur J Vasc Endovasc Surg. 2003;26(4):374-80. [pmid: 14511998].
Fransson T, Thorne J. In situ saphenous vein bypass grafting - still first line treatment? A prospective study comparing surgical results between diabetic and non-diabetic populations. Vasa. 2010;39(1):59-65. [pmid: 20186677].
Gardner AW, Killewich LA, Montgomery PS, et al. Response to exercise rehabilitation in smoking and nonsmoking patients with intermittent claudication. J Vasc Surg. 2004;39(3):531-8. [pmid: 14981444].
Goodney PP, Schanzer A, Demartino RR, et al. Validation of the Society for Vascular Surgery's objective performance goals for critical limb ischemia in everyday vascular surgery practice. J Vasc Surg. 2011;54(1):100-8.e4. [pmid: 21334173].
Gray BH, Olin JW. Limitations of percutaneous transluminal angioplasty with stenting for femoropopliteal arterial occlusive disease. Semin Vasc Surg. 1997;10(1):8-16. [pmid: 9068071].
Green RM, Donarye C, Deweese JA. Autogenous venous bypass grafts and limb salvage: 5-year results in 1971 and 1991. Cardiovasc Surg. 1995;3(4):425-30. [pmid: 7582999].
Gresele P, Migliacci R, Di Sante G, et al. Effect of cloricromene on intermittent claudication. A randomized, double-blind, placebo-controlled trial in patients treated with aspirin: effect on claudication distance and quality of life. CRAMPS Investigator Group. Cloricromene Randomized Arteriopathy Multicenter Prospective Study. Vasc Med. 2000;5(2):83-9. [pmid: 10943584].
Gruss JD. Effects of adjuvant PGE1 therapy following profundaplasty in patients with severe limb ischaemia. Early and long-term results. Vasa. 1997;26(2):117-21. [pmid: 9174388].
Heider P, Wildgruber M, Wolf O, et al. Improvement of microcirculation after percutaneous transluminal angioplasty in the lower limb with prostaglandin E1. Prostaglandins Other Lipid Mediat. 2009;88(1-2):23-30. [pmid: 18832042].
Heneghan HM, Sultan S. Homocysteine, the cholesterol of the 21st century. Impact of hyperhomocysteinemia on patency and amputation-free survival after intervention for critical limb ischemia. J Endovasc Ther. 2008;15(4):399-407. [pmid: 18729558].
Hiatt WR, Creager MA, Amato A, et al. Effect of propionyl-L-carnitine on a background of monitored exercise in patients with claudication secondary to peripheral artery disease. J Cardiopulm Rehabil Prev. 2011;31(2):125-32. [pmid: 20861750].
Hingorani A, Ascher E, Markevich N, et al. The role of the endovascular surgeon for lower extremity ischemia. Acta Chir Belg. 2004;104(5):527-31. [pmid: 15571018].
Ho GH, Moll FL, Eikelboom BC, et al. Endarterectomy of the superficial femoral artery. Semin Vasc Surg. 1995;8(3):216-24. [pmid: 8564035].
Iida O, Nanto S, Uematsu M, et al. Cilostazol reduces restenosis after endovascular therapy in patients with femoropopliteal lesions. J Vasc Surg. 2008;48(1):144-9. [pmid: 18482817].
Illnait J, Castano G, Alvarez E, et al. Effects of policosanol (10 mg/d) versus aspirin (100 mg/d) in patients with intermittent claudication: a 10-week, randomized, comparative study. Angiology. 2008;59(3):269-77. [pmid: 18388038].
Jackson MR, Johnson WC, Williford WO, et al. The effect of anticoagulation therapy and graft selection on the ischemic consequences of femoropopliteal bypass graft occlusion: results from a multicenter randomized clinical trial. J Vasc Surg. 2002;35(2):292-8. [pmid: 11854727].
Jaff MR, Dale RA, Creager MA, et al. Anti-chlamydial antibiotic therapy for symptom improvement in peripheral artery disease: prospective evaluation of rifalazil effect on vascular symptoms of intermittent claudication and other endpoints in Chlamydia pneumoniae seropositive patients (PROVIDENCE-1). Circulation. 2009;119(3):452-8. [pmid: 19139383].
Jain KM, O'brien SP, Munn JS, et al. Axillobifemoral bypass: elective versus emergent operation. Ann Vasc Surg. 1998;12(3):265-9. [pmid: 9588514].
Jivegard L, Drott C, Gelin J, et al. Effects of three months of low molecular weight heparin (dalteparin) treatment after bypass surgery for lower limb ischemia--a randomised placebo-controlled double blind multicentre trial. Eur J Vasc Endovasc Surg. 2005;29(2):190-8. [pmid: 15649728].
Johnson WC, Williford WO. Benefits, morbidity, and mortality associated with long-term administration of oral anticoagulant therapy to patients with peripheral arterial bypass procedures: a prospective randomized study. J Vasc Surg. 2002;35(3):413-21. [pmid: 11877686].
Johnson WC, Williford WO, Corson JD, et al. Hemorrhagic complications during long-term postoperative warfarin administration in patients undergoing lower extremity arterial bypass surgery. Vascular. 2004;12(6):362-8. [pmid: 15895759].
Kaputin M, Ovcharenko DV, Platonov SA, et al. Comparative analysis of remote results of transluminal balloon angioplasty in treatment of lower limb critical ischaemia in groups of patients with and without diabetes mellitus. Angiol Sosud Khir. 2010;16(3):41-6. [pmid: 21275231].
Kavros SJ, Delis KT, Turner NS, et al. Improving limb salvage in critical ischemia with intermittent pneumatic compression: a controlled study with 18-month follow-up. J Vasc Surg. 2008;47(3):543-9. [pmid: 18295105].
Klevsgard R, Hallberg IR, Risberg B, et al. The effects of successful intervention on quality of life in patients with varying degrees of lower-limb ischaemia. Eur J Vasc Endovasc Surg. 2000;19(3):238-45. [pmid: 10753686].
Klevsgard R, Risberg BO, Thomsen MB, et al. A 1-year follow-up quality of life study after hemodynamically successful or unsuccessful surgical revascularization of lower limb ischemia. J Vasc Surg. 2001;33(1):114-22. [pmid: 11137931].
Ko YG, Shin S, Kim KJ, et al. Efficacy of stent-supported subintimal angioplasty in the treatment of long iliac artery occlusions. J Vasc Surg. 2011;54(1):116-22. [pmid: 21334171].
Koch M, Trapp R, Hepp W. Impact of femoropopliteal bypass surgery on the survival and amputation rate of end-stage renal disease patients with critical limb ischemia. Med Klin (Munich). 2007;102(2):107-11. [pmid: 17323017].
Koppensteiner R, Spring S, Amann-Vesti BR, et al. Low-molecular-weight heparin for prevention of restenosis after femoropopliteal percutaneous transluminal angioplasty: a randomized controlled trial. J Vasc Surg. 2006;44(6):1247-53. [pmid: 17145426].
Kreatsoulas C, Anand SS. Disparity in outcomes of surgical revascularization for limb salvage. Race and gender are synergistic determinants of vein graft failure and limb loss. Nguyen LL, Hevelone N, Rogers SO, Bandyk DF, Clowes AW, Moneta GL, Lipsitz S, Conte MS. Circulation. 2009; 119: 123-130. Vasc Med. 2009;14(4):397-9. [pmid: 19808727].
Kudo T, Chandra FA, Ahn SS. Long-term outcomes and predictors of iliac angioplasty with selective stenting. J Vasc Surg. 2005;42(3):466-75. [pmid: 16171589].
Kudo T, Chandra FA, Ahn SS. The effectiveness of percutaneous transluminal angioplasty for the treatment of critical limb ischemia: a 10-year experience. J Vasc Surg. 2005;41(3):423-35. discussion 435. [pmid: 15838475].
Kudo T, Rigberg DA, Reil TD, et al. The influence of the ipsilateral superficial femoral artery on iliac angioplasty. Ann Vasc Surg. 2006;20(4):502-11. [pmid: 16732446].
Kumada Y, Aoyama T, Ishii H, et al. Long-term outcome of percutaneous transluminal angioplasty in chronic haemodialysis patients with peripheral arterial disease. Nephrol Dial Transplant. 2008;23(12):3996-4001. [pmid: 18596131].
Kumar BN, Gambhir RP. Critical limb ischemia-need to look beyond limb salvage. Ann Vasc Surg. 2011;25(7):873-7. [pmid: 21831588].
Lam RC, Shah S, Faries PL, et al. Incidence and clinical significance of distal embolization during percutaneous interventions involving the superficial femoral artery. J Vasc Surg. 2007;46(6):1155-9. [pmid: 18154991].
Lantis JC 2nd, Conte MS, Belkin M, et al. Infrainguinal bypass grafting in patients with end-stage renal disease: improving outcomes?. J Vasc Surg. 2001;33(6):1171-8. [pmid: 11389414].
Laxdal E, Eide GE, Wirsching J, et al. Homocysteine levels, haemostatic risk factors and patency rates after endovascular treatment of the above-knee femoro-popliteal artery. Eur J Vasc Endovasc Surg. 2004;28(4):410-7. [pmid: 15350565].
Lesiak T, Mikosinski J, Piskorz L, et al. Evaluation of combined, conservative treatment impact on the clinical course, blood flow parameters and muscle perfussion in the group of patients with newly diagnosed, untreated peripheral arterial disease (PAD). Clin Exp Med Lett. 2010;51(2):123-9.
Letterstal A, Forsberg C, Olofsson P, et al. Risk attitudes to treatment among patients with severe intermittent claudication. J Vasc Surg. 2008;47(5):988-94. [pmid: 18455642].
Leu AJ, Schneider E, Canova CR, et al. Long-term results after recanalisation of chronic iliac artery occlusions by combined catheter therapy without stent placement. Eur J Vasc Endovasc Surg. 1999;18(6):499-505. [pmid: 10637146].
Lofberg AM, Lorelius LE, Karacagil S, et al. The use of below-knee percutaneous transluminal angioplasty in arterial occlusive disease causing chronic critical limb ischemia. Cardiovasc Intervent Radiol. 1996;19(5):317-22. [pmid: 8781151].
Luther M, Lepantalo M. Arterial reconstruction to the foot arteries--a viable option?. Eur J Surg. 1997;163(9):659-65. [pmid: 9311472].
Luther M, Lepantalo M. Infrainguinal reconstructions: influence of surgical experience on outcome. Cardiovasc Surg. 1998;6(4):351-7. [pmid: 9725513].
Luther M. Surgical treatment for chronic critical leg ischaemia: a 5 year follow-up of socioeconomic outcome. Eur J Vasc Endovasc Surg. 1997;13(5):452-9. [pmid: 9166267].
Manzi M, Fusaro M, Ceccacci T, et al. Clinical results of below-the knee intervention using pedal-plantar loop technique for the revascularization of foot arteries. J Cardiovasc Surg (Torino). 2009;50(3):331-7. [pmid: 19543193].
Marin ML, Veith FJ, Sanchez LA, et al. Endovascular repair of aortoiliac occlusive disease. World J Surg. 1996;20(6):679-86. [pmid: 8662152].
Martens JM, Knippenberg B, Vos JA, et al. Update on PADI trial: percutaneous transluminal angioplasty and drug-eluting stents for infrapopliteal lesions in critical limb ischemia. J Vasc Surg. 2009;50(3):687-9. [pmid: 19700099].
Marzelle J, Fichelle JM, Cormier F, et al. Outcome of infrainguinal endovascular revascularization procedures for limb-threatening ischemia. Ann Vasc Surg. 1995;9(Suppl):S24-31. [pmid: 8688306].
Maxwell AJ, Anderson BE, Cooke JP. Nutritional therapy for peripheral arterial disease: a double-blind, placebo-controlled, randomized trial of HeartBar. Vasc Med. 2000;5(1):11-9. [pmid: 10737151].
Mazari FA, Carradice D, Rahman MN, et al. An analysis of relationship between quality of life indices and clinical improvement following intervention in patients with intermittent claudication due to femoropopliteal disease. J Vasc Surg. 2010;52(1):77-84. [pmid: 20471779].
Melliere D, Berrahal D, Desgranges P, et al. Influence of diabetes on revascularisation procedures of the aorta and lower limb arteries: early results. Eur J Vasc Endovasc Surg. 1999;17(5):438-41. [pmid: 10329530].
Mijailovic M, Lukic S. Limb salvage procedure in occlusion of the infrapopliteal arteries. Vojnosanit Pregl. 2007;64(2):135-8. [pmid: 17348466].
Mirenda F, La Spada M, Baccellieri D, et al. Iloprost infusion in diabetic patients with peripheral arterial occlusive disease and foot ulcers. Chir Ital. 2005;57(6):731-5. [pmid: 16400768].
Mobin-Uddin K, Vincent GS, Evans WE. Prevention of anastomotic intimal hyperplasia in infrainguinal PTFE bypass grafts with distal arterial segment interposition. Vasc Surg. 1999;33(3):269-81.
Mohler ER 3rd, Gainer JL, Whitten K, et al. Evaluation of trans sodium crocetinate on safety and exercise performance in patients with peripheral artery disease and intermittent claudication. Vasc Med. 2011;16(5):346-53. [pmid: 22003000].
Munoz-Torrero JF, Escudero D, Suarez C, et al. Concomitant use of proton pump inhibitors and clopidogrel in patients with coronary, cerebrovascular, or peripheral artery disease in the factores de Riesgo y ENfermedad Arterial (FRENA) registry. J Cardiovasc Pharmacol. 2011;57(1):13-9. [pmid: 21164357].
Nehler MR, Brass EP, Anthony R, et al. Adjunctive parenteral therapy with lipo-ecraprost, a prostaglandin E1 analog, in patients with critical limb ischemia undergoing distal revascularization does not improve 6-month outcomes. J Vasc Surg. 2007;45(5):953-60. discussion 960-1. [pmid: 17350216].
Nenci GG, Gresele P, Ferrari G, et al. Treatment of intermittent claudication with mesoglycan--a placebo-controlled, double-blind study. Thromb Haemost. 2001;86(5):1181-7. [pmid: 11816704].
Neri Serneri GG, Coccheri S, Marubini E, et al. Picotamide, a combined inhibitor of thromboxane A2 synthase and receptor, reduces 2-year mortality in diabetics with peripheral arterial disease: the DAVID study. Eur Heart J. 2004;25(20):1845-52. [pmid: 15474700].
Neville RF, Dy B, Singh N, et al. Distal vein patch with an arteriovenous fistula: a viable option for the patient without autogenous conduit and severe distal occlusive disease. J Vasc Surg. 2009;50(1):83-8. [pmid: 19563955].
Nguyen BN, Conrad MF, Guest JM, et al. Late outcomes of balloon angioplasty and angioplasty with selective stenting for superficial femoral-popliteal disease are equivalent. J Vasc Surg. 2011;54(4):1051-7 e1. [pmid: 21636240].
Nguyen LL, Hevelone N, Rogers SO, et al. Disparity in outcomes of surgical revascularization for limb salvage: race and gender are synergistic determinants of vein graft failure and limb loss. Circulation. 2009;119(1):123-30. [pmid: 19103988].
Nguyen LL, Moneta GL, Conte MS, et al. Prospective multicenter study of quality of life before and after lower extremity vein bypass in 1404 patients with critical limb ischemia. J Vasc Surg. 2006;44(5):977-83. discussion 983-4. [pmid: 17098529].
Ogawa H, Nakayama M, Morimoto T, et al. Low-dose aspirin for primary prevention of atherosclerotic events in patients with type 2 diabetes: a randomized controlled trial. JAMA. 2008;300(18):2134-41. [pmid: 18997198].
Oka RK, Altman M, Giacomini JC, et al. Abnormal cardiovascular response to exercise in patients with peripheral arterial disease: Implications for management. J Vasc Nurs. 2005;23(4):130-6. quiz 137-8. [pmid: 16326331].
Ortmann J, Gahl B, Diehm N, et al. Survival benefits of revascularization in patients with critical limb ischemia and renal insufficiency. J Vasc Surg. 2012;56(3):737-45 e1. [pmid: 22677008].
Ortmann J, Nesch E, Cajori G, et al. Benefit of immediate revascularization in women with critical limb ischemia in an intention-to-treat analysis. J Vasc Surg. 2011;54(6):1668-78 e1. [pmid: 22035761].
Oser RF, Picus D, Hicks ME, et al. Accuracy of DSA in the evaluation of patency of infrapopliteal vessels. J Vasc Interv Radiol. 1995;6(4):589-94. [pmid: 7579870].
Owens CD, Ho KJ, Kim S, et al. Refinement of survival prediction in patients undergoing lower extremity bypass surgery: stratification by chronic kidney disease classification. J Vasc Surg. 2007;45(5):944-52. [pmid: 17391900].
Panchenko E, Eshkeeva A, Dobrovolsky A, et al. Effects of indobufen and pentoxifylline on walking capacity and hemostasis in patients with intermittent claudication: results of six months of treatment. Angiology. 1997;48(3):247-54. [pmid: 9071201].
Panneton JM, Gloviczki P, Bower TC, et al. Pedal bypass for limb salvage: impact of diabetes on long-term outcome. Ann Vasc Surg. 2000;14(6):640-7. [pmid: 11128460].
Passman MA, Marston WA, Carlin RE, et al. Long-term results of infrapopliteal bypass using polytetrafluoroethylene and Taylor vein patch for critical lower extremity ischemia. Vasc Surg. 2000;34(6):569-76.
Paumier A, Abraham P, Mahe G, et al. Functional outcome of hypogastric revascularisation for prevention of buttock claudication in patients with peripheral artery occlusive disease. Eur J Vasc Endovasc Surg. 2010;39(3):323-9. [pmid: 19910224].
Peeters P, Verbist J, Deloose K, et al. Results with heparin bonded polytetrafluoroethylene grafts for femorodistal bypasses. J Cardiovasc Surg (Torino). 2006;47(4):407-13. [pmid: 16953160].
Peregrin JH, Smirova S, Koznar B, et al. Self-expandable stent placement in infrapopliteal arteries after unsuccessful angioplasty failure: one-year follow-up. Cardiovasc Intervent Radiol. 2008;31(5):860-4. [pmid: 18236105].
Plate G, Qvarfordt P, Oredsson S, et al. Obturator bypass to the distal profunda femoris artery using a medial approach--long-term results. Eur J Vasc Endovasc Surg. 1998;16(2):164-8. [pmid: 9728438].
Plecha EJ, Lee C, Hye RJ. Factors influencing the outcome of paramalleolar bypass grafts. Ann Vasc Surg. 1996;10(4):356-60. [pmid: 8879390].
Pomposelli FB Jr, Arora S, Gibbons GW, et al. Lower extremity arterial reconstruction in the very elderly: successful outcome preserves not only the limb but also residential status and ambulatory function. J Vasc Surg. 1998;28(2):215-25. [pmid: 9719316].
Rabellino M, Aragon-Sanchez J, Gonzalez G, et al. Is endovascular revascularisation worthwhile in diabetic patients with critical limb ischemia who also have end-stage renal disease?. Diabetes Res Clin Pract. 2010;90(3):e79-81. [pmid: 21030104].
Raffetto JD, Chen MN, Lamorte WW, et al. Factors that predict site of outflow target artery anastomosis in infrainguinal revascularization. J Vasc Surg. 2002;35(6):1093-9. [pmid: 12042719].
Ramaswami G, D'ayala M, Hollier LH, et al. Rapid foot and calf compression increases walking distance in patients with intermittent claudication: results of a randomized study. J Vasc Surg. 2005;41(5):794-801. [pmid: 15886663].
Randon C, Jacobs B, De Ryck F, et al. Fifteen years of infrapopliteal arterial reconstructions with cryopreserved venous allografts for limb salvage. J Vasc Surg. 2010;51(4):869-77. [pmid: 20347683].
Rastan A, Schwarzwalder U, Noory E, et al. Primary use of sirolimus-eluting stents in the infrapopliteal arteries. J Endovasc Ther. 2010;17(4):480-7. [pmid: 20681763].
Rauwerda JA. Surgical treatment of the infected diabetic foot. Diabetes Metab Res Rev. 2004;20(Suppl 1):S41-4. [pmid: 15150813].
Ray SA, Buckenham TM, Belli AM, et al. The predictive value of laser Doppler fluxmetry and transcutaneous oximetry for clinical outcome in patients undergoing revascularisation for severe leg ischaemia. Eur J Vasc Endovasc Surg. 1997;13(1):54-9. [pmid: 9046915].
Ray SA, Rowley MR, Bevan DH, et al. Hypercoagulable abnormalities and postoperative failure of arterial reconstruction. Eur J Vasc Endovasc Surg. 1997;13(4):363-70. [pmid: 9133987].
Rhee SY, Kim YS, Chon S, et al. Long-term effects of cilostazol on the prevention of macrovascular disease in patients with type 2 diabetes mellitus. Diabetes Res Clin Pract. 2011;91(1):e11-4. [pmid: 20934769].
Rossi PJ, Skelly CL, Meyerson SL, et al. Redo infrainguinal bypass: factors predicting patency and limb salvage. Ann Vasc Surg. 2003;17(5):492-502. [pmid: 12958672].
Rzucidlo EM, Powell RJ, Zwolak RM, et al. Early results of stent-grafting to treat diffuse aortoiliac occlusive disease. J Vasc Surg. 2003;37(6):1175-80. [pmid: 12764261].
Sarkar R, Ro KM, Obrand DI, et al. Lower extremity vascular reconstruction and endovascular surgery without preoperative angiography. Am J Surg. 1998;176(2):203-7. [pmid: 9737633].
Scatena A, Petruzzi P, Ferrari M, et al. Outcomes of three years of teamwork on critical limb ischemia in patients with diabetes and foot lesions. Int J Low Extrem Wounds. 2012;11(2):113-9. [pmid: 22665920].
Schmidt A, Piorkowski M, Werner M, et al. First experience with drug-eluting balloons in infrapopliteal arteries: restenosis rate and clinical outcome. J Am Coll Cardiol. 2011;58(11):1105-9. [pmid: 21884945].
Schneider PA, Abcarian PW, Ogawa DY, et al. Should balloon angioplasty and stents have any role in operative intervention for lower extremity ischemia?. Ann Vasc Surg. 1997;11(6):574-80. [pmid: 9363302].
Schneider PA, Caps MT, Nelken N. Infrainguinal vein graft stenosis: cutting balloon angioplasty as the first-line treatment of choice. J Vasc Surg. 2008;47(5):960-6. discussion 966. [pmid: 18372146].
Schneider PA, Caps MT, Ogawa DY, et al. Intraoperative superficial femoral artery balloon angioplasty and popliteal to distal bypass graft: an option for combined open and endovascular treatment of diabetic gangrene. J Vasc Surg. 2001;33(5):955-62. [pmid: 11331834].
Schneider PA, Ogawa DY, Rush MP. Lower extremity revascularization without contrast arteriography: a prospective study of operation based upon duplex mapping. Cardiovasc Surg. 1999;7(7):699-703. [pmid: 10639043].
Scott EC, Biuckians A, Light RE, et al. Subintimal angioplasty for the treatment of claudication and critical limb ischemia: 3-year results. J Vasc Surg. 2007;46(5):959-64. [pmid: 17905560].
Scott EC, Biuckians A, Light RE, et al. Subintimal angioplasty: Our experience in the treatment of 506 infrainguinal arterial occlusions. J Vasc Surg. 2008;48(4):878-84. [pmid: 18586445].
Seabrook GR, Cambria RA, Freischlag JA, et al. Health-related quality of life and functional outcome following arterial reconstruction for limb salvage. Cardiovasc Surg. 1999;7(3):279-86. [pmid: 10386743].
Shah AP, Klein AJ, Sterrett A, et al. Clinical outcomes using aggressive approach to anatomic screening and endovascular revascularization in a veterans affairs population with critical limb ischemia. Catheter Cardiovasc Interv. 2009;74(1):11-9. [pmid: 19360870].
Shammas NW, Dippel EJ, Amidon C, et al. In-hospital complications in treating chronic limb ischemia: The feasibility of alternative anticoagulation therapy to unfractionated heparin. Vasc Dis Manage. 2006;3(6):376-8.
Sigvant B, Henriksson M, Lundin F, et al. Asymptomatic peripheral arterial disease: is pharmacological prevention of cardiovascular risk cost-effective?. Eur J Cardiovasc Prev Rehabil. 2011;18(2):254-61. [pmid: 21450673].
Simo G, Banga P, Darabos G, et al. Stent-assisted Remote Iliac Artery Endarterectomy: An Alternative Approach to Treating Combined External Iliac and Common Femoral Artery Disease. Eur J Vasc Endovasc Surg. 2011;42(5):648-55. [pmid: 21704539].
Simsir SA, Cabellon A, Kohlman-Trigoboff D, et al. Factors influencing limb salvage and survival after amputation and revascularization in patients with end-stage renal disease. Am J Surg. 1995;170(2):113-7. [pmid: 7631913].
Smeets L, Ho GH, Hagenaars T, et al. Remote endarterectomy: first choice in surgical treatment of long segmental SFA occlusive disease?. Eur J Vasc Endovasc Surg. 2003;25(6):583-9. [pmid: 12787704].
Soder HK, Manninen HI, Jaakkola P, et al. Prospective trial of infrapopliteal artery balloon angioplasty for critical limb ischemia: angiographic and clinical results. J Vasc Interv Radiol. 2000;11(8):1021-31. [pmid: 10997465].
Soder HK, Manninen HI, Rasanen HT, et al. Failure of prolonged dilation to improve long-term patency of femoropopliteal artery angioplasty: results of a prospective trial. J Vasc Interv Radiol. 2002;13(4):361-9. [pmid: 11932366].
Soga Y, Iida O, Hirano K, et al. Impact of cilostazol after endovascular treatment for infrainguinal disease in patients with critical limb ischemia. J Vasc Surg. 2011;54(6):1659-67. [pmid: 21872419].
Soga Y, Iida O, Hirano K, et al. Restenosis after stent implantation for superficial femoral artery disease in patients treated with cilostazol. Catheter Cardiovasc Interv. 2011;79(4):541-8. [pmid: 21805619].
Spinosa DJ, Harthun NL, Bissonette EA, et al. Subintimal arterial flossing with antegrade-retrograde intervention (SAFARI) for subintimal recanalization to treat chronic critical limb ischemia. J Vasc Interv Radiol. 2005;16(1):37-44. [pmid: 15640408].
Stanisic M, Winckiewicz M, Majewska N. Evaluation of the criteria influencing certification regarding the ability to work on patients after open or endovascular operations on the arterial system of lower limbs. Acta Angiolog. 2008;14(1):9-17.
Stone PA, Armstrong PA, Bandyk DF, et al. Duplex ultrasound criteria for femorofemoral bypass revision. J Vasc Surg. 2006;44(3):496-502. [pmid: 16950423].
Strano A. Propionyl-L-carnitine versus pentoxifylline: Improvement in walking capacity in patients with intermittent claudication. Clin Drug Invest. 2002;22(Suppl 1):1-6.
Suding PN, Mcmaster W, Hansen E, et al. Increased endovascular interventions decrease the rate of lower limb artery bypass operations without an increase in major amputation rate. Ann Vasc Surg. 2008;22(2):195-9. [pmid: 18346571].
Szymaska J, Nowotny J, et al. The effect of high tone power therapy on gait range in patients with chronic lower limb ischaemia. Ortop Traumatol Rehabil. 2011;13(3):279-92. [pmid: 21750358].
Taylor MD, Napolitano LM. Methicillin-resistant Staphylococcus aureus infections in vascular surgery: increasing prevalence. Surg Infect (Larchmt). 2004;5(2):180-7. [pmid: 15353115].
Taylor SM, Kalbaugh CA, Blackhurst DW, et al. A comparison of percutaneous transluminal angioplasty versus amputation for critical limb ischemia in patients unsuitable for open surgery. J Vasc Surg. 2007;45(2):304-10. discussion 310-1. [pmid: 17264008].
Taylor SM, Kalbaugh CA, Healy MG, et al. Do current outcomes justify more liberal use of revascularization for vasculogenic claudication? A single center experience of 1,000 consecutively treated limbs. J Am Coll Surg. 2008;206(5):1053-62. discussion 1062-4. [pmid: 18471755].
Taylor SM, Langan EM 3rd, Snyder BA, et al. Superficial femoral artery eversion endarterectomy: a useful adjunct for infrainguinal bypass in the presence of limited autogenous vein. J Vasc Surg. 1997;26(3):439-45. discussion 445-6. [pmid: 9308589].
Tebbutt N, Robinson L, Todhunter J, et al. A plantar flexion device exercise programme for patients with peripheral arterial disease: a randomised prospective feasibility study. Physiotherapy. 2011;97(3):244-9. [pmid: 21820543].
Thorne J, Danielsson G, Danielsson P, et al. Intraoperative angioscopy may improve the outcome of in situ saphenous vein bypass grafting: a prospective study. J Vasc Surg. 2002;35(4):759-65. [pmid: 11932676].
Tielbeek AV, Vroegindeweij D, Buth J, et al. Comparison of intravascular ultrasonography and intraarterial digital subtraction angiography after directional atherectomy of short lesions in femoropopliteal arteries. J Vasc Surg. 1996;23(3):436-45. [pmid: 8601885].
Tisi PV, Mirnezami A, Baker S, et al. Role of subintimal angioplasty in the treatment of chronic lower limb ischaemia. Eur J Vasc Endovasc Surg. 2002;24(5):417-22. [pmid: 12435341].
Tonnesen KH, Holstein P, Rordam L, et al. Early results of percutaneous transluminal angioplasty (PTA) of failing below-knee bypass grafts. Eur J Vasc Endovasc Surg. 1998;15(1):51-6. [pmid: 9519000].
Treiman GS, Schneider PA, Lawrence PF, et al. Does stent placement improve the results of ineffective or complicated iliac artery angioplasty?. J Vasc Surg. 1998;28(1):104-12. discussion 113-4. [pmid: 9685136].
Treiman GS, Treiman R, Whiting J. Results of percutaneous subintimal angioplasty using routine stenting. J Vasc Surg. 2006;43(3):513-9. [pmid: 16520165].
Ubbink DT, Tulevski Ii, Legemate DA, et al. Diabetes mellitus is not a contra-indication for peripheral vascular intervention in patients with leg ischemia. Vasa. 1997;26(1):39-42. [pmid: 9163236].
Uccioli L, Gandini R, Giurato L, et al. Long-term outcomes of diabetic patients with critical limb ischemia followed in a tertiary referral diabetic foot clinic. Diabetes Care. 2010;33(5):977-82. [pmid: 20200304].
Van Dijk LC, Van Urk H, Du Bois NA, et al. A new “closed” in situ vein bypass technique results in a reduced wound complication rate. Eur J Vasc Endovasc Surg. 1995;10(2):162-7. [pmid: 7655967].
Virkkunen J, Heikkinen M, Lepantalo M, et al. Diabetes as an independent risk factor for early postoperative complications in critical limb ischemia. J Vasc Surg. 2004;40(4):761-7. [pmid: 15472606].
Voellinger DG, Jordan WD Jr. Video-assisted vein harvest: A single institution's experience of 103 peripheral bypass cases. Vasc Surg. 1998;32(6):545-57.
Vouyouka AG, Egorova NN, Salloum A, et al. Lessons learned from the analysis of gender effect on risk factors and procedural outcomes of lower extremity arterial disease. J Vasc Surg. 2010;52(5):1196-202. [pmid: 20674247].
Wann-Hansson C, Hallberg IR, Risberg B, et al. A comparison of the Nottingham Health Profile and Short Form 36 Health Survey in patients with chronic lower limb ischaemia in a longitudinal perspective. Health Qual Life Outcomes. 2004;2:9. [pmid: 14969590].
Weaver FA, Comerota AJ, Youngblood M, et al. Surgical revascularization versus thrombolysis for nonembolic lower extremity native artery occlusions: results of a prospective randomized trial. The STILE Investigators. Surgery versus Thrombolysis for Ischemia of the Lower Extremity. J Vasc Surg. 1996;24(4):513-21. discussion 521-3. [pmid: 8911400].
Welten GM, Schouten O, Hoeks SE, et al. Long-term prognosis of patients with peripheral arterial disease: a comparison in patients with coronary artery disease. J Am Coll Cardiol. 2008;51(16):1588-96. [pmid: 18420103].
Werneck CC, Lindsay TF. Tibial angioplasty for limb salvage in high-risk patients and cost analysis. Ann Vasc Surg. 2009;23(5):554-9. [pmid: 19632085].
Wilson YG, Davies AH, Currie IC, et al. Vein graft stenosis: incidence and intervention. Eur J Vasc Endovasc Surg. 1996;11(2):164-9. [pmid: 8616647].
Wixon CL, Mills JL, Westerband A, et al. An economic appraisal of lower extremity bypass graft maintenance. J Vasc Surg. 2000;32(1):1-12. [pmid: 10876201].
Yoshida RDA, Matida CK, Sobreira ML, et al. Comparative study of evolution and survival of patients with intermittent claudication, with or without limitation for exercises, followed in a specific outpatient setting. J Vasc Bras. 2008;7(2):112-22.
Zachry WM, Wilson JP, Lawson KA, et al. Procedure costs and outcomes associated with pharmacologic management of peripheral arterial disease in the Department of Defense. Clin Ther. 1999;21(8):1358-69. [pmid: 10485507].
Zukauskas G, Ulevicius H. Simultaneous versus two-stage multisegmental reconstruction for critical lower limb ischemia. Ann Saudi Med. 1995;15(4):333-8. [pmid: 17590601].
Zukauskas G, Ulevicius H, Janusauskas E. Re-do operations after failed multisegmental reconstructive arterial surgery for critical limb ischaemia. Cardiovasc Surg. 1997;5(4):419-23. [pmid: 9350799].

## Does not include primary or secondary outcomes of interest

Berger K, Hessel F, Kreuzer J, et al. Clopidogrel versus aspirin in patients with atherothrombosis: CAPRIE-based calculation of cost-effectiveness for Germany. Curr Med Res Opin. 2008;24(1):267-74. [pmid: 18053318].
Bradbury A, Wilmink T, Lee AJ, et al. Bypass versus angioplasty to treat severe limb ischemia: factors that affect treatment preferences of UK surgeons and interventional radiologists. J Vasc Surg. 2004;39(5):1026-32. [pmid: 15111856].
Bramer SL, Forbes WP, Mallikaarjun S. Cilostazol pharmacokinetics after single and multiple oral doses in healthy males and patients with intermittent claudication resulting from peripheral arterial disease. Clin Pharmacokinet. 1999;37(Suppl 2):1-11. [pmid: 10702882].
Cleanthis M, Bhattacharya V, Smout J, et al. Combined aspirin and cilostazol treatment is associated with reduced platelet aggregation and prevention of exercise-induced platelet activation. Eur J Vasc Endovasc Surg. 2009;37(5):604-10. [pmid: 19297212].
Cleanthis M, Smout J, Bhattacharya V, et al. Treadmill exercise in claudicants on aspirin results in improved antioxidant status but only minimal platelet activation. Platelets. 2005;16(8):446-52. [pmid: 16287611].
Cox MH, Robison JG, Brothers TE, et al. Contemporary analysis of outcomes following lower extremity bypass in patients with end-stage renal disease. Ann Vasc Surg. 2001;15(3):374-82. [pmid: 11414090].
Crowther RG, Spinks WL, Leicht AS, et al. The influence of a long term exercise program on lower limb movement variability and walking performance in patients with peripheral arterial disease. Hum Mov Sci. 2009;28(4):494-503. [pmid: 19435644].
Duscha BD, Robbins JL, Jones WS, et al. Angiogenesis in Skeletal Muscle Precede Improvements in Peak Oxygen Uptake in Peripheral Artery Disease Patients. Arterioscler Thromb Vasc Biol. 2011;31(11):2742-8. [pmid: 21868709].
Heredero AF, Acin F, March JR, et al. Impact of endovascular surgery on management of critical lower-limb ischemia in a vascular surgery department. Vasc Endovascular Surg. 2005;39(5):429-35. [pmid: 16193216].
Hiatt WR, Regensteiner JG, Wolfel EE, et al. Effect of exercise training on skeletal muscle histology and metabolism in peripheral arterial disease. J Appl Physiol. 1996;81(2):780-8. [pmid: 8872646].
Huisinga JM, Pipinos Ii, Johanning JM, et al. The effect of pharmacological treatment on gait biomechanics in peripheral arterial disease patients. J Neuroeng Rehabil. 2010;7:25. [pmid: 20529284].
Incandela L, De Sanctis MT, Cesarone MR, et al. Short-range intermittent claudication and rest pain: microcirculatory effects of pentoxifylline in a randomized, controlled trial. Angiology. 2002;53(Suppl 1):S27-30. [pmid: 11865832].
Singh S, Evans L, Datta D, et al. The costs of managing lower limb-threatening ischaemia. Eur J Vasc Endovasc Surg. 1996;12(3):359-62. [pmid: 8896481].
Smout JD, Mikhailidis DP, Shenton BK, et al. Combination antiplatelet therapy in patients with peripheral vascular bypass grafts. Clin Appl Thromb Hemost. 2004;10(1):9-18. [pmid: 14979400].
Sung RS, Althoen M, Howell TA, et al. Peripheral vascular occlusive disease in renal transplant recipients: risk factors and impact on kidney allograft survival. Transplantation. 2000;70(7):1049-54. [pmid: 11045641].
Taft C, Sullivan M, Lundholm K, et al. Predictors of treatment outcome in intermittent claudication. Eur J Vasc Endovasc Surg. 2004;27(1):24-32. [pmid: 14652833].
Van Asselt AD, Nicolai SP, Joore MA, et al. Cost-effectiveness of exercise therapy in patients with intermittent claudication: supervised exercise therapy versus a 'go home and walk' advice. Eur J Vasc Endovasc Surg. 2011;41(1):97-103. [pmid: 21159527].
Van Dijk LC, Seerden R, Van Urk H, et al. Comparison of cost affecting parameters and costs of the “closed” and “open” in situ bypass technique. Eur J Vasc Endovasc Surg. 1997;13(5):460-3. [pmid: 9166268].
Varela C, Acin F, De Haro J, et al. The role of foot collateral vessels on ulcer healing and limb salvage after successful endovascular and surgical distal procedures according to an angiosome model. Vasc Endovascular Surg. 2010;44(8):654-60. [pmid: 20675308].
Wilhite DB, Comerota AJ, Schmieder FA, et al. Managing PAD with multiple platelet inhibitors: the effect of combination therapy on bleeding time. J Vasc Surg. 2003;38(4):710-3. [pmid: 14560218].
Wyttenbach R, Gallino A, Alerci M, et al. Effects of percutaneous transluminal angioplasty and endovascular brachytherapy on vascular remodeling of human femoropopliteal artery by noninvasive magnetic resonance imaging. Circulation. 2004;110(9):1156-61. [pmid: 15326071].
Zeltsman D, Kerstein MD. Sociology of care in patients with severe peripheral vascular disease. Am Surg. 1998;64(2):175-7. [pmid: 9486893].
Ziegler S, Maca T, Alt E, et al. Monitoring of antiplatelet therapy with the PFA-100 in peripheral angioplasty patients. Platelets. 2002;13(8):493-7. [pmid: 12487783].

## Single treatment strategy comparison

Abou-Zamzam AM Jr, Moneta GL, Lee RW, et al. Peroneal bypass is equivalent to inframalleolar bypass for ischemic pedal gangrene. Arch Surg. 1996;131(8):894-8. discussion 988-9. [pmid: 8712916].
Aburahma AF, Hayes JD, Flaherty SK, et al. Primary iliac stenting versus transluminal angioplasty with selective stenting. J Vasc Surg. 2007;46(5):965-70. [pmid: 17905559].
Albers M, Fratezi AC, De Luccia N. Walking ability and quality of life as outcome measures in a comparison of arterial reconstruction and leg amputation for the treatment of vascular disease. Eur J Vasc Endovasc Surg. 1996;11(3):308-14. [pmid: 8601241].
Alexandrescu V, Vincent G, Azdad K, et al. A reliable approach to diabetic neuroischemic foot wounds: below-the-knee angiosome-oriented angioplasty. J Endovasc Ther. 2011;18(3):376-87. [pmid: 21679080].
Alimi Y, Di Mauro P, Barthelemy P, et al. Iliac transluminal angioplasty and distal surgical revascularisation can be performed in a one-step technique. Int Angiol. 1997;16(2):83-7. [pmid: 9257667].
Allen BT, Reilly JM, Rubin BG, et al. Femoropopliteal bypass for claudication: vein vs PTFE. Ann Vasc Surg. 1996;10(2):178-85. [pmid: 8733871].
Allen JD, Stabler T, Kenjale A, et al. Plasma nitrite flux predicts exercise performance in peripheral arterial disease after 3months of exercise training. Free Radic Biol Med. 2010;49(6):1138-44. [pmid: 20620208].
Amighi J, Schillinger M, Dick P, et al. De novo superficial femoropopliteal artery lesions: peripheral cutting balloon angioplasty and restenosis rates--randomized controlled trial. Radiology. 2008;247(1):267-72. [pmid: 18270378].
Anonymous. PTFE bypass to below-knee arteries: distal vein collar or not? A prospective randomised multicentre study. Eur J Vasc Endovasc Surg. 2010;39(6):747-54. [pmid: 20236841].
Arnold TE, Kerstein MD. Secondary distal extension of infrainguinal bypass: long-term limb and patient survival. Ann Vasc Surg. 2000;14(5):450-6. [pmid: 10990553].
Bacourt F. Prospective randomized study of carbon-impregnated polytetrafluoroethylene grafts for below-knee popliteal and distal bypass: results at 2 years. The Association Universitaire de Recherche en Chirurgie. Ann Vasc Surg. 1997;11(6):596-603. [pmid: 9363305].
Bakken AM, Saad WE, Davies MG. Cryoballoon angioplasty broadens the role of primary angioplasty and reduces adjuvant stenting in complex superficial femoral artery lesions. J Am Coll Surg. 2008;206(3):524-32. [pmid: 18308225].
Ballotta E, Renon L, De Rossi A, et al. Prospective randomized study on reversed saphenous vein infrapopliteal bypass to treat limb-threatening ischemia: common femoral artery versus superficial femoral or popliteal and tibial arteries as inflow. J Vasc Surg. 2004;40(4):732-40. [pmid: 15472602].
Ballotta E, Renon L, Toffano M, et al. Prospective randomized study on bilateral above-knee femoropopliteal revascularization: Polytetrafluoroethylene graft versus reversed saphenous vein. J Vasc Surg. 2003;38(5):1051-5. [pmid: 14603216].
Bastounis E, Georgopoulos S, Maltezos C, et al. PTFE-vein composite grafts for critical limb ischaemia: a valuable alternative to all-autogenous infrageniculate reconstructions. Eur J Vasc Endovasc Surg. 1999;18(2):127-32. [pmid: 10426969].
Battaglia G, Tringale R, Monaca V. Retrospective comparison of a heparin bonded ePTFE graft and saphenous vein for infragenicular bypass: implications for standard treatment protocol. J Cardiovasc Surg (Torino). 2006;47(1):41-7. [pmid: 16434944].
Becquemin JP, Favre JP, Marzelle J, et al. Systematic versus selective stent placement after superficial femoral artery balloon angioplasty: a multicenter prospective randomized study. J Vasc Surg. 2003;37(3):487-94. [pmid: 12618680].
Bonvini R, Baumgartner I, Do DD, et al. Late acute thrombotic occlusion after endovascular brachytherapy and stenting of femoropopliteal arteries. J Am Coll Cardiol. 2003;41(3):409-12. [pmid: 12575967].
Bosch JL, Van Der Graaf Y, Hunink MG. Health-related quality of life after angioplasty and stent placement in patients with iliac artery occlusive disease: results of a randomized controlled clinical trial. The Dutch Iliac Stent Trial Study Group. Circulation. 1999;99(24):3155-60. [pmid: 10377079].
Bosiers M, Hart JP, Deloose K, et al. Endovascular therapy as the primary approach for limb salvage in patients with critical limb ischemia: experience with 443 infrapopliteal procedures. Vascular. 2006;14(2):63-9. [pmid: 16956473].
Bosiers M, Peeters P, D'archambeau O, et al. AMS INSIGHT--absorbable metal stent implantation for treatment of below-the-knee critical limb ischemia: 6-month analysis. Cardiovasc Intervent Radiol. 2009;32(3):424-35. [pmid: 19093148].
Bosiers M, Scheinert D, Peeters P, et al. Randomized comparison of everolimus-eluting versus bare-metal stents in patients with critical limb ischemia and infrapopliteal arterial occlusive disease. J Vasc Surg. 2012;55(2):390-8. [pmid: 22169682].
Boufi M, Dona B, Orsini B, et al. A comparison of the standard bolia technique versus subintimal recanalization plus Viabahn stent graft in the management of femoro-popliteal occlusions. J Vasc Surg. 2010;52(5):1211-7. [pmid: 20692789].
Brass EP, Cooper LT, Morgan RE, et al. A phase II dose-ranging study of the phosphodiesterase inhibitor K-134 in patients with peripheral artery disease and claudication. J Vasc Surg. 2012;55(2):381-9 e1. [pmid: 22119244].
Brothers TE, Robison JG, Elliott BM. Diabetes mellitus is the major risk factor for African Americans who undergo peripheral bypass graft operation. J Vasc Surg. 1999;29(2):352-9. [pmid: 9950993].
Burger DH, Kappetein AP, Van Bockel JH, et al. A prospective randomized trial comparing vein with polytetrafluoroethylene in above-knee femoropopliteal bypass grafting. J Vasc Surg. 2000;32(2):278-83. [pmid: 10917987].
Carmeli E, Barchad S, Masharawi Y, et al. Impact of a walking program in people with down syndrome. J Strength Cond Res. 2004;18(1):180-4. [pmid: 14971963].
Cejna M, Thurnher S, Illiasch H, et al. PTA versus Palmaz stent placement in femoropopliteal artery obstructions: a multicenter prospective randomized study. J Vasc Interv Radiol. 2001;12(1):23-31. [pmid: 11200349].
Cheetham DR, Burgess L, Ellis M, et al. Does supervised exercise offer adjuvant benefit over exercise advice alone for the treatment of intermittent claudication? A randomised trial. Eur J Vasc Endovasc Surg. 2004;27(1):17-23. [pmid: 14652832].
Chew DK, Nguyen LL, Owens CD, et al. Comparative analysis of autogenous infrainguinal bypass grafts in African Americans and Caucasians: the association of race with graft function and limb salvage. J Vasc Surg. 2005;42(4):695-701. [pmid: 16242557].
Ciocon JO, Galindo-Ciocon D, Galindo DJ. A comparison between aspirin and pentoxifylline in relieving claudication due to peripheral vascular disease in the elderly. Angiology. 1997;48(3):237-40. [pmid: 9071199].
Collins EG, Edwin Langbein W, Orebaugh C, et al. PoleStriding exercise and vitamin E for management of peripheral vascular disease. Med Sci Sports Exerc. 2003;35(3):384-93. [pmid: 12618567].
Collins EG, Langbein WE, Orebaugh C, et al. Cardiovascular training effect associated with polestriding exercise in patients with peripheral arterial disease. J Cardiovasc Nurs. 2005;20(3):177-85. [pmid: 15870588].
Creager MA, Pande RL, Hiatt WR. A randomized trial of iloprost in patients with intermittent claudication. Vasc Med. 2008;13(1):5-13. [pmid: 18372433].
Davidovic L, Jakovljevic N, Radak D, et al. Dacron or ePTFE graft for above-knee femoropopliteal bypass reconstruction. A bi-centre randomised study. Vasa. 2010;39(1):77-84. [pmid: 20186679].
Degischer S, Labs KH, Hochstrasser J, et al. Physical training for intermittent claudication: a comparison of structured rehabilitation versus home-based training. Vasc Med. 2002;7(2):109-15. [pmid: 12402991].
Derubertis BG, Vouyouka A, Rhee SJ, et al. Percutaneous intervention for infrainguinal occlusive disease in women: equivalent outcomes despite increased severity of disease compared with men. J Vasc Surg. 2008;48(1):150-7. discussion 157-8. [pmid: 18589232].
Devine C, Mccollum C. Heparin-bonded Dacron or polytetrafluorethylene for femoropopliteal bypass: five-year results of a prospective randomized multicenter clinical trial. J Vasc Surg. 2004;40(5):924-31. [pmid: 15557906].
Devine C, Hons B, Mccollum C. Heparin-bonded Dacron or polytetrafluoroethylene for femoropopliteal bypass grafting: a multicenter trial. J Vasc Surg. 2001;33(3):533-9. [pmid: 11241124].
Di Salvo MM, Ardita G, Giani L, et al. Comparison between intravenous iloprost and vasoactive drugs in limb ischemia IIB severe. A retrospective analysis. Minerva Cardioangiol. 2006;54(3):377-81. [pmid: 16733512].
Dick P, Wallner H, Sabeti S, et al. Balloon angioplasty versus stenting with nitinol stents in intermediate length superficial femoral artery lesions. Catheter Cardiovasc Interv. 2009;74(7):1090-5. [pmid: 19859954].
Dorigo W, Pulli R, Castelli P, et al. A multicentric comparison between autologous saphenous vein and heparin-bonded expanded polytetrafluoroethylene (ePTFE) graft in the treatment of critical limb ischemia in diabetics. J Vasc Surg. 2011;54(5):1332-8. [pmid: 21840151].
Duda SH, Bosiers M, Lammer J, et al. Drug-eluting and bare nitinol stents for the treatment of atherosclerotic lesions in the superficial femoral artery: long-term results from the SIROCCO trial. J Endovasc Ther. 2006;13(6):701-10. [pmid: 17154704].
Duda SH, Bosiers M, Lammer J, et al. Sirolimus-eluting versus bare nitinol stent for obstructive superficial femoral artery disease: the SIROCCO II trial. J Vasc Interv Radiol. 2005;16(3):331-8. [pmid: 15758128].
Duda SH, Pusich B, Richter G, et al. Sirolimus-eluting stents for the treatment of obstructive superficial femoral artery disease: six-month results. Circulation. 2002;106(12):1505-9. [pmid: 12234956].
Eiberg JP, Roder O, Stahl-Madsen M, et al. Fluoropolymer-coated dacron versus PTFE grafts for femorofemoral crossover bypass: randomised trial. Eur J Vasc Endovasc Surg. 2006;32(4):431-8. [pmid: 16807001].
Fakhry F, Spronk S, De Ridder M, et al. Long-term effects of structured home-based exercise program on functional capacity and quality of life in patients with intermittent claudication. Arch Phys Med Rehabil. 2011;92(7):1066-73. [pmid: 21704786].
Fisher CM, Fletcher JP, May J, et al. No additional benefit from laser in balloon angioplasty of the superficial femoral artery. Eur J Vasc Endovasc Surg. 1996;11(3):349-52. [pmid: 8601248].
Fowler B, Jamrozik K, Norman P, et al. Improving maximum walking distance in early peripheral arterial disease: randomised controlled trial. Aust J Physiother. 2002;48(4):269-75. [pmid: 12443521].
Gardner AW, Montgomery PS. The Baltimore activity scale for intermittent claudication: a validation study. Vasc Endovascular Surg. 2006;40(5):383-91. [pmid: 17038572].
Gardner AW, Katzel LI, Sorkin JD, et al. Exercise rehabilitation improves functional outcomes and peripheral circulation in patients with intermittent claudication: a randomized controlled trial. J Am Geriatr Soc. 2001;49(6):755-62. [pmid: 11454114].
Gardner AW, Montgomery PS, Flinn WR, et al. The effect of exercise intensity on the response to exercise rehabilitation in patients with intermittent claudication. J Vasc Surg. 2005;42(4):702-9. [pmid: 16242558].
Gisbertz SS, Ramzan M, Tutein Nolthenius RP, et al. Short-term results of a randomized trial comparing remote endarterectomy and supragenicular bypass surgery for long occlusions of the superficial femoral artery [the REVAS trial]. Eur J Vasc Endovasc Surg. 2009;37(1):68-76. [pmid: 18990592].
Gisbertz SS, Tutein Nolthenius RP, De Borst GJ, et al. Remote endarterectomy versus supragenicular bypass surgery for long occlusions of the superficial femoral artery: medium-term results of a randomized controlled trial (the REVAS trial). Ann Vasc Surg. 2010;24(8):1015-23. [pmid: 21035693].
Green RM, Abbott WM, Matsumoto T, et al. Prosthetic above-knee femoropopliteal bypass grafting: five-year results of a randomized trial. J Vasc Surg. 2000;31(3):417-25. [pmid: 10709052].
Grimm J, Muller-Hulsbeck S, Jahnke T, et al. Randomized study to compare PTA alone versus PTA with Palmaz stent placement for femoropopliteal lesions. J Vasc Interv Radiol. 2001;12(8):935-42. [pmid: 11487673].
Grizzo Cucato G, De Moraes Forjaz CL, Kanegusuku H, et al. Effects of walking and strength training on resting and exercise cardiovascular responses in patients with intermittent claudication. Vasa. 2011;40(5):390-7. [pmid: 21948782].
Gupta AK, Bandyk DF, Cheanvechai D, et al. Natural history of infrainguinal vein graft stenosis relative to bypass grafting technique. J Vasc Surg. 1997;25(2):211-20. discussion 220-5. [pmid: 9052556].
Hamsho A, Nott D, Harris PL. Prospective randomised trial of distal arteriovenous fistula as an adjunct to femoro-infrapopliteal PTFE bypass. Eur J Vasc Endovasc Surg. 1999;17(3):197-201. [pmid: 10092890].
Hepp W, Von BaE, Corovic I, et al. Clinical efficacy of IV prostaglandin E1 and IV pentoxifylline in patients with arterial occlusive disease of Fontaine stage IIb: A multicenter, randomized comparative study. Int J Angiol. 1996;5(1):32-7.
Hertzer NR, Bena JF, Karafa MT. A personal experience with direct reconstruction and extra-anatomic bypass for aortoiliofemoral occlusive disease. J Vasc Surg. 2007;45(3):527-35. discussion 535. [pmid: 17321340].
Hertzer NR, Bena JF, Karafa MT. A personal experience with the influence of diabetes and other factors on the outcome of infrainguinal bypass grafts for occlusive disease. J Vasc Surg. 2007;46(2):271-9. [pmid: 17600656].
Hodges LD, Sandercock GR, Das SK, et al. Randomized controlled trial of supervised exercise to evaluate changes in cardiac function in patients with peripheral atherosclerotic disease. Clin Physiol Funct Imaging. 2008;28(1):32-7. [pmid: 18005078].
Hoedt MT, Van Urk H, Hop WC, et al. A comparison of distal end-to-side and end-to-end anastomoses in femoropopliteal bypasses. Eur J Vasc Endovasc Surg. 2001;21(3):266-70. [pmid: 11352686].
Huisinga JM, Pipinos Ii, Stergiou N, et al. Treatment with pharmacological agents in peripheral arterial disease patients does not result in biomechanical gait changes. J Appl Biomech. 2010;26(3):341-8. [pmid: 20841626].
Hultgren R, Olofsson P, Wahlberg E. Gender differences in patients treated for critical limb ischemia. Eur J Vasc Endovasc Surg. 2005;29(3):295-300. [pmid: 15694804].
Imfeld S, Singer L, Degischer S, et al. Quality of life improvement after hospital- based rehabilitation or home-based physical training in intermittent claudication. Vasa. 2006;35(3):178-84. [pmid: 16941407].
Ishii H, Kumada Y, Toriyama T, et al. Effects of oral cilostazol 100 mg BID on long-term patency after percutaneous transluminal angioplasty in patients with femoropopliteal disease undergoing hemodialysis: a retrospective chart review in Japanese patients. Clin Ther. 2010;32(1):24-33. [pmid: 20171408].
Izquierdo-Porrera AM, Gardner AW, Powell CC, et al. Effects of exercise rehabilitation on cardiovascular risk factors in older patients with peripheral arterial occlusive disease. J Vasc Surg. 2000;31(4):670-7. [pmid: 10753274].
Jackson MR, Ali AT, Bell C, et al. Aortofemoral bypass in young patients with premature atherosclerosis: is superficial femoral vein superior to Dacron?. J Vasc Surg. 2004;40(1):17-23. [pmid: 15218456].
Jackson MR, Belott TP, Dickason T, et al. The consequences of a failed femoropopliteal bypass grafting: comparison of saphenous vein and PTFE grafts. J Vasc Surg. 2000;32(3):498-504. 504. 5. [pmid: 10957656].
Jensen LP, Lepantalo M, Fossdal JE, et al. Dacron or PTFE for above-knee femoropopliteal bypass. a multicenter randomised study. Eur J Vasc Endovasc Surg. 2007;34(1):44-9. [pmid: 17400486].
Johnson WC, Lee KK. Comparative evaluation of externally supported Dacron and polytetrafluoroethylene prosthetic bypasses for femorofemoral and axillofemoral arterial reconstructions. Veterans Affairs Cooperative Study #141. J Vasc Surg. 1999;30(6):1077-83. [pmid: 10587392].
Jones PP, Skinner JS, Smith LK, et al. Functional improvements following StairMaster vs. treadmill exercise training for patients with intermittent claudication. J Cardiopulm Rehabil. 1996;16(1):47-55. [pmid: 8907442].
Kakkos SK, Geroulakos G, Nicolaides AN. Improvement of the walking ability in intermittent claudication due to superficial femoral artery occlusion with supervised exercise and pneumatic foot and calf compression: a randomised controlled trial. Eur J Vasc Endovasc Surg. 2005;30(2):164-75. [pmid: 15890545].
Kapfer X, Meichelboeck W, Groegler FM. Comparison of carbon-impregnated and standard ePTFE prostheses in extra-anatomical anterior tibial artery bypass: a prospective randomized multicenter study. Eur J Vasc Endovasc Surg. 2006;32(2):155-68. [pmid: 16617028].
Karnabatidis D, Spiliopoulos S, Diamantopoulos A, et al. Primary everolimus-eluting stenting versus balloon angioplasty with bailout bare metal stenting of long infrapopliteal lesions for treatment of critical limb ischemia. J Endovasc Ther. 2011;18(1):1-12. [pmid: 21314342].
Killewich LA, Macko RF, Montgomery PS, et al. Exercise training enhances endogenous fibrinolysis in peripheral arterial disease. J Vasc Surg. 2004;40(4):741-5. [pmid: 15472603].
Kimura H, Miyata T, Sato O, et al. Infrainguinal arterial reconstruction for limb salvage in patients with end-stage renal disease. Eur J Vasc Endovasc Surg. 2003;25(1):29-34. [pmid: 12525808].
Klein WM, Van Der Graaf Y, Seegers J, et al. Long-term cardiovascular morbidity, mortality, and reintervention after endovascular treatment in patients with iliac artery disease: The Dutch Iliac Stent Trial Study. Radiology. 2004;232(2):491-8. [pmid: 15286319].
Klinkert P, Schepers A, Burger DH, et al. Vein versus polytetrafluoroethylene in above-knee femoropopliteal bypass grafting: five-year results of a randomized controlled trial. J Vasc Surg. 2003;37(1):149-55. [pmid: 12514593].
Kobayashi M, Hida K, Shikata H, et al. Long term outcome of femoropopliteal bypass for claudication and critical ischemia. Asian Cardiovasc Thorac Ann. 2004;12(3):208-12. [pmid: 15353457].
Koscielny A, Putz U, Willinek W, et al. Case-control comparison of profundaplasty and femoropopliteal supragenicular bypass for peripheral arterial disease. Br J Surg. 2010;97(3):344-8. [pmid: 20101647].
Koskela VK, Salenius J, Suominen V. Peripheral arterial disease in octogenarians and nonagenarians: factors predicting survival. Ann Vasc Surg. 2011;25(2):169-76. [pmid: 20926240].
Krajcer Z, Sioco G, Reynolds T. Comparison of Wallgraft and Wallstent for treatment of complex iliac artery stenosis and occlusion. Preliminary results of a prospective randomized study. Tex Heart Inst J. 1997;24(3):193-9. [pmid: 9339507].
Krankenberg H, Schluter M, Steinkamp HJ, et al. Nitinol stent implantation versus percutaneous transluminal angioplasty in superficial femoral artery lesions up to 10 cm in length: the femoral artery stenting trial (FAST). Circulation. 2007;116(3):285-92. [pmid: 17592075].
Kreienberg PB, Darling RC 3rd, Chang BB, et al. Early results of a prospective randomized trial of spliced vein versus polytetrafluoroethylene graft with a distal vein cuff for limb-threatening ischemia. J Vasc Surg. 2002;35(2):299-306. [pmid: 11854728].
Laird JR, Katzen BT, Scheinert D, et al. Nitinol stent implantation versus balloon angioplasty for lesions in the superficial femoral artery and proximal popliteal artery: twelve-month results from the RESILIENT randomized trial. Circ Cardiovasc Interv. 2010;3(3):267-76. [pmid: 20484101].
Langbein WE, Collins EG, Orebaugh C, et al. Increasing exercise tolerance of persons limited by claudication pain using polestriding. J Vasc Surg. 2002;35(5):887-93. [pmid: 12021703].
Larena-Avellaneda A, Russmann S, Fein M, et al. Prophylactic use of the silver-acetate-coated graft in arterial occlusive disease: a retrospective, comparative study. J Vasc Surg. 2009;50(4):790-8. [pmid: 19660894].
Laurila K, Lepantalo M, Teittinen K, et al. Does an adjuvant AV-fistula improve the patency of a femorocrural PTFE bypass with distal vein cuff in critical leg ischaemia?--a prospective randomised multicentre trial. Eur J Vasc Endovasc Surg. 2004;27(2):180-5. [pmid: 14718901].
Lawson JA, Tangelder MJ, Algra A, et al. The myth of the in situ graft: superiority in infrainguinal bypass surgery?. Eur J Vasc Endovasc Surg. 1999;18(2):149-57. [pmid: 10428752].
Lee TM, Su SF, Tsai CH, et al. Differential effects of cilostazol and pentoxifylline on vascular endothelial growth factor in patients with intermittent claudication. Clin Sci (Lond). 2001;101(3):305-11. [pmid: 11524048].
Lindholt JS, Gottschalksen B, Johannesen N, et al. The Scandinavian Propaten((R)) trial - 1-year patency of PTFE vascular prostheses with heparin-bonded luminal surfaces compared to ordinary pure PTFE vascular prostheses - a randomised clinical controlled multi-centre trial. Eur J Vasc Endovasc Surg. 2011;41(5):668-73. [pmid: 21376643].
Lu CH, Chang J, Lai ST, et al. Comparative evaluation of stretch and non-stretch polytetrafluorethylene (PTFE) prosthetic grafts for femoro-popliteal bypass. Zhonghua Yi Xue Za Zhi (Taipei). 2002;65(5):200-4. [pmid: 12166763].
Madiba TE, Mars M, Robbs JV. Aorto-iliac occlusive disease in the different population groups--clinical pattern, risk profile and results of reconstruction. S Afr Med J. 1999;89(12):1288-92. [pmid: 10678200].
Madiba TE, Mars M, Robbs JV. Choosing the proximal anastomosis in aortobifemoral bypass. Br J Surg. 1997;84(10):1416-8. [pmid: 9361602].
Manfredini F, Malagoni AM, Mascoli F, et al. Training rather than walking: the test in -train out program for home-based rehabilitation in peripheral arteriopathy. Circ J. 2008;72(6):946-52. [pmid: 18503221].
Martinez CA, Carmeli E, Barak S, et al. Changes in pain-free walking based on time in accommodating pain-free exercise therapy for peripheral arterial disease. J Vasc Nurs. 2009;27(1):2-7. [pmid: 19217538].
Matarazzo A, Rosati Tarulli V, Florio A, et al. Chronic critical ischaemia of the lower extremities. G Ital Chir Vasc. 2000;7(4):309-15.
Matsubara J, Sakamoto S, Yamamoto K, et al. Externally Supported, Noncoated, Knitted Dacron Graft and Gelatin-Coated Knitted Dacron Graft with Rings for Peripheral Arterial Reconstruction. Int J Angiol. 2000;9(2):103-6. [pmid: 10758206].
Matzke S, Pitkanen J, Lepantalo M. Does saphenous vein arterialisation prevent major amputation in critical leg ischaemia? A comparative study. J Cardiovasc Surg (Torino). 1999;40(6):845-7. [pmid: 10776715].
Mcdermott MM, Ades P, Guralnik JM, et al. Treadmill exercise and resistance training in patients with peripheral arterial disease with and without intermittent claudication: a randomized controlled trial. JAMA. 2009;301(2):165-74. [pmid: 19141764].
Mcdermott MM, Liu K, Ferrucci L, et al. Physical performance in peripheral arterial disease: a slower rate of decline in patients who walk more. Ann Intern Med. 2006;144(1):10-20. [pmid: 16389250].
Mcdermott MM, Tiukinhoy S, Greenland P, et al. A pilot exercise intervention to improve lower extremity functioning in peripheral arterial disease unaccompanied by intermittent claudication. J Cardiopulm Rehabil. 2004;24(3):187-96. [pmid: 15235301].
Meister RH, Schweiger H, Lang W. Knitted double-velour Dacron prostheses in aortobifemoral position--long-term performance of different coating materials. Vasa. 1998;27(4):236-9. [pmid: 9859745].
Meneses AL, De Lima GH, Forjaz CL, et al. Impact of a supervised strength training or walking training over a subsequent unsupervised therapy period on walking capacity in patients with claudication. J Vasc Nurs. 2011;29(2):81-6. [pmid: 21558030].
Mika P, Spodaryk K, Cencora A, et al. Experimental model of pain-free treadmill training in patients with claudication. Am J Phys Med Rehabil. 2005;84(10):756-62. [pmid: 16205431].
Mika P, Spodaryk K, Cencora A, et al. Red blood cell deformability in patients with claudication after pain-free treadmill training. Clin J Sport Med. 2006;16(4):335-40. [pmid: 16858218].
Nawaz S, Walker RD, Wilkinson CH, et al. The inflammatory response to upper and lower limb exercise and the effects of exercise training in patients with claudication. J Vasc Surg. 2001;33(2):392-9. [pmid: 11174795].
Nicolai SP, Hendriks EJ, Prins MH, et al. Optimizing supervised exercise therapy for patients with intermittent claudication. J Vasc Surg. 2010;52(5):1226-33. [pmid: 20692797].
Nicolai SP, Teijink JA, Prins MH. Multicenter randomized clinical trial of supervised exercise therapy with or without feedback versus walking advice for intermittent claudication. J Vasc Surg. 2010;52(2):348-55. [pmid: 20478681].
Oderich GS, Panneton JM, Yagubyan M, et al. Comparison of precuffed and vein-cuffed expanded polytetrafluoroethylene grafts for infragenicular arterial reconstructions: a case-matched study. Ann Vasc Surg. 2005;19(1):49-55. [pmid: 15714367].
O'donnell ME, Badger SA, Sharif MA, et al. The effects of cilostazol on exercise-induced ischaemia-reperfusion injury in patients with peripheral arterial disease. Eur J Vasc Endovasc Surg. 2009;37(3):326-35. [pmid: 19112032].
O'donnell ME, Badger SA, Sharif MA, et al. The vascular and biochemical effects of cilostazol in patients with peripheral arterial disease. J Vasc Surg. 2009;49(5):1226-34. [pmid: 19217745].
Onohara T, Komori K, Kume M, et al. Multivariate analysis of long-term results after an axillobifemoral and aortobifemoral bypass in patients with aortoiliac occlusive disease. J Cardiovasc Surg (Torino). 2000;41(6):905-10. [pmid: 11232974].
Oostenbrink JB, Tangelder MJ, Busschbach JJ, et al. Cost-effectiveness of oral anticoagulants versus aspirin in patients after infrainguinal bypass grafting surgery. J Vasc Surg. 2001;34(2):254-62. [pmid: 11496277].
Palumbo N, Cevolani M, Paragona O, et al. Revascularization of the peroneal artery in chronic critical leg ischemia. G Ital Chir Vasc. 2000;7(2):105-13.
Panayiotopoulos YP, Taylor PR. A paper for debate: vein versus PTFE for critical limb ischaemia--an unfair comparison?. Eur J Vasc Endovasc Surg. 1997;14(3):191-4. [pmid: 9345238].
Panneton JM, Hollier LH, Hofer JM. Multicenter randomized prospective trial comparing a precuffed polytetrafluoroethylene graft to a vein cuffed polytetrafluoroethylene graft for infragenicular arterial bypass. Ann Vasc Surg. 2004;18(2):199-206. [pmid: 15253256].
Parr BM, Noakes TD, Derman EW. Peripheral arterial disease and intermittent claudication: efficacy of short-term upper body strength training, dynamic exercise training, and advice to exercise at home. S Afr Med J. 2009;99(11):800-4. [pmid: 20218480].
Passman MA, Taylor LM, Moneta GL, et al. Comparison of axillofemoral and aortofemoral bypass for aortoiliac occlusive disease. J Vasc Surg. 1996;23(2):263-9. discussion 269-71. [pmid: 8637103].
Pinto BM, Marcus BH, Patterson RB, et al. On-site versus home exercise programs: psychological benefits for individuals with arterial claudication. J Aging Phys Act. 1997;5(4):311-28.
Plecha EJ, Freischlag JA, Seabrook GR, et al. Femoropopliteal bypass revisited: an analysis of 138 cases. Cardiovasc Surg. 1996;4(2):195-9. [pmid: 8861436].
Ponec D, Jaff MR, Swischuk J, et al. The Nitinol SMART stent vs Wallstent for suboptimal iliac artery angioplasty: CRISP-US trial results. J Vasc Interv Radiol. 2004;15(9):911-8. [pmid: 15361558].
Pozzi Mucelli F, Fisicaro M, Calderan L, et al. Percutaneous revascularization of femoropopliteal artery disease: PTA and PTA plus stent. Results after six years' follow-up. Radiol Med. 2003;105(4):339-49. [pmid: 12835627].
Pullatt R, Brothers TE, Robison JG, et al. Compromised bypass graft outcomes after minimal-incision vein harvest. J Vasc Surg. 2006;44(2):289-94. discussion 294-5. [pmid: 16890856].
Rabellino M, Zander T, Baldi S, et al. Clinical follow-up in endovascular treatment for TASC C-D lesions in femoro-popliteal segment. Catheter Cardiovasc Interv. 2009;73(5):701-5. [pmid: 19309709].
Rand T, Basile A, Cejna M, et al. PTA versus carbofilm-coated stents in infrapopliteal arteries: pilot study. Cardiovasc Intervent Radiol. 2006;29(1):29-38. [pmid: 16252079].
Rand T, Lammer J, Rabbia C, et al. Percutaneous transluminal angioplasty versus turbostatic carbon-coated stents in infrapopliteal arteries: InPeria II trial. Radiology. 2011;261(2):634-42. [pmid: 22012905].
Randon C, Jacobs B, De Ryck F, et al. Angioplasty or primary stenting for infrapopliteal lesions: results of a prospective randomized trial. Cardiovasc Intervent Radiol. 2010;33(2):260-9. [pmid: 19957178].
Raouf AA, Rouleau Y, Clement A, et al. Stentgraft and concomitant infrainguinal revascularization in complex iliac occlusive disease: A retrospective study and follow-up in 22 cases. Chirurgia. 2008;21(2):57-61.
Raptis S, Miller JH. Influence of a vein cuff on polytetrafluoroethylene grafts for primary femoropopliteal bypass. Br J Surg. 1995;82(4):487-91. [pmid: 7613892].
Rastan A, Tepe G, Krankenberg H, et al. Sirolimus-eluting stents vs. bare-metal stents for treatment of focal lesions in infrapopliteal arteries: a double-blind, multi-centre, randomized clinical trial. Eur Heart J. 2011;32(18):2274-81. [pmid: 21622669].
Regensteiner JG, Meyer TJ, Krupski WC, et al. Hospital vs home-based exercise rehabilitation for patients with peripheral arterial occlusive disease. Angiology. 1997;48(4):291-300. [pmid: 9112877].
Regensteiner JG, Steiner JF, Hiatt WR. Exercise training improves functional status in patients with peripheral arterial disease. J Vasc Surg. 1996;23(1):104-15. [pmid: 8558725].
Ricco JB, Probst H. Long-term results of a multicenter randomized study on direct versus crossover bypass for unilateral iliac artery occlusive disease. J Vasc Surg. 2008;47(1):45-53. discussion 53-4. [pmid: 17997269].
Ritti-Dias RM, Wolosker N, De Moraes Forjaz CL, et al. Strength training increases walking tolerance in intermittent claudication patients: randomized trial. J Vasc Surg. 2010;51(1):89-95. [pmid: 19837534].
Robinson BI, Fletcher JP. Fluoropolymer coated Dacron or polytetrafluoroethylene for femoropopliteal bypass grafting: a multicentre trial. ANZ J Surg. 2003;73(3):95-9. [pmid: 12608965].
Robinson BI, Fletcher JP, Tomlinson P, et al. A prospective randomized multicentre comparison of expanded polytetrafluoroethylene and gelatin-sealed knitted Dacron grafts for femoropopliteal bypass. Cardiovasc Surg. 1999;7(2):214-8. [pmid: 10353674].
Sabeti S, Czerwenka-Wenkstetten A, Dick P, et al. Quality of life after balloon angioplasty versus stent implantation in the superficial femoral artery: findings from a randomized controlled trial. J Endovasc Ther. 2007;14(4):431-7. [pmid: 17696615].
Sabeti S, Schillinger M, Amighi J, et al. Primary patency of femoropopliteal arteries treated with nitinol versus stainless steel self-expanding stents: propensity score-adjusted analysis. Radiology. 2004;232(2):516-21. [pmid: 15286322].
Sadek M, Ellozy SH, Turnbull IC, et al. Improved outcomes are associated with multilevel endovascular intervention involving the tibial vessels compared with isolated tibial intervention. J Vasc Surg. 2009;49(3):638-43. discussion 643-4. [pmid: 19268768].
Sala F, Hassen-Khodja R, Lecis A, et al. Long-term outcome of femoral above-knee popliteal artery bypass using autologous saphenous vein versus expanded polytetrafluoroethylene grafts. Ann Vasc Surg. 2003;17(4):401-7. [pmid: 14670018].
Sanderson B, Askew C, Stewart I, et al. Short-term effects of cycle and treadmill training on exercise tolerance in peripheral arterial disease. J Vasc Surg. 2006;44(1):119-27. [pmid: 16828435].
Sarac TP, Huber TS, Back MR, et al. Warfarin improves the outcome of infrainguinal vein bypass grafting at high risk for failure. J Vasc Surg. 1998;28(3):446-57. [pmid: 9737454].
Savage P, Ricci MA, Lynn M, et al. Effects of home versus supervised exercise for patients with intermittent claudication. J Cardiopulm Rehabil. 2001;21(3):152-7. [pmid: 11409225].
Saxon RR, Coffman JM, Gooding JM, et al. Long-term results of ePTFE stent-graft versus angioplasty in the femoropopliteal artery: single center experience from a prospective, randomized trial. J Vasc Interv Radiol. 2003;14(3):303-11. [pmid: 12631634].
Saxon RR, Dake MD, Volgelzang RL, et al. Randomized, multicenter study comparing expanded polytetrafluoroethylene-covered endoprosthesis placement with percutaneous transluminal angioplasty in the treatment of superficial femoral artery occlusive disease. J Vasc Interv Radiol. 2008;19(6):823-32. [pmid: 18503895].
Saxton JM, Zwierska I, Blagojevic M, et al. Upper- versus lower-limb aerobic exercise training on health-related quality of life in patients with symptomatic peripheral arterial disease. J Vasc Surg. 2011;53(5):1265-73. [pmid: 21215558].
Sayers RD, Raptis S, Berce M, et al. Long-term results of femorotibial bypass with vein or polytetrafluoroethylene. Br J Surg. 1998;85(7):934-8. [pmid: 9692567].
Schillinger M, Sabeti S, Dick P, et al. Sustained benefit at 2 years of primary femoropopliteal stenting compared with balloon angioplasty with optional stenting. Circulation. 2007;115(21):2745-9. [pmid: 17502568].
Schillinger M, Sabeti S, Loewe C, et al. Balloon angioplasty versus implantation of nitinol stents in the superficial femoral artery. N Engl J Med. 2006;354(18):1879-88. [pmid: 16672699].
Schlager O, Dick P, Sabeti S, et al. Long-segment SFA stenting--the dark sides: in-stent restenosis, clinical deterioration, and stent fractures. J Endovasc Ther. 2005;12(6):676-84. [pmid: 16363897].
Schmieder GC, Richardson AI, Scott EC, et al. Selective stenting in subintimal angioplasty: analysis of primary stent outcomes. J Vasc Surg. 2008;48(5):1175-80. discussion 1180-1. [pmid: 18778911].
Semaan E, Hamburg N, Nasr W, et al. Endovascular management of the popliteal artery: comparison of atherectomy and angioplasty. Vasc Endovascular Surg. 2010;44(1):25-31. [pmid: 19942598].
Setacci F, Sirignano P, Raucci A, et al. Below the knee endovascular revascularization strategy for limb salvage in diabetic patients. Ital J Vasc Endovasc Surg. 2010;17(3):189-94.
Siablis D, Karnabatidis D, Katsanos K, et al. Infrapopliteal application of sirolimus-eluting versus bare metal stents for critical limb ischemia: analysis of long-term angiographic and clinical outcome. J Vasc Interv Radiol. 2009;20(9):1141-50. [pmid: 19620014].
Siablis D, Karnabatidis D, Katsanos K, et al. Sirolimus-eluting versus bare stents after suboptimal infrapopliteal angioplasty for critical limb ischemia: enduring 1-year angiographic and clinical benefit. J Endovasc Ther. 2007;14(2):241-50. [pmid: 17484536].
Siablis D, Kraniotis P, Karnabatidis D, et al. Sirolimus-eluting versus bare stents for bailout after suboptimal infrapopliteal angioplasty for critical limb ischemia: 6-month angiographic results from a nonrandomized prospective single-center study. J Endovasc Ther. 2005;12(6):685-95. [pmid: 16363898].
Singer E, Imfeld S, Staub D, et al. Effect of aspirin versus clopidogrel on walking exercise performance in intermittent claudication-a double-blind randomized multicenter trial. J Am Heart Assoc. 2012;1(1):51-6. [pmid: 23130118].
Singh S, Singh H, Kohli A, et al. Effects of cilostazole and pentoxifylline on claudication distance and lipid profile in patients with occlusive peripheral arterial disease: A comparative trial. Indian J Thorac Cardiovasc Surg. 2009;25(2):45-8.
Slim H, Tiwari A, Ahmed A, et al. Distal versus ultradistal bypass grafts: amputation-free survival and patency rates in patients with critical leg ischaemia. Eur J Vasc Endovasc Surg. 2011;42(1):83-8. [pmid: 21514854].
Slordahl SA, Wang E, Hoff J, et al. Effective training for patients with intermittent claudication. Scand Cardiovasc J. 2005;39(4):244-9. [pmid: 16118073].
Smeets L, Ho GH, Tangelder MJ, et al. Outcome after occlusion of infrainguinal bypasses in the Dutch BOA Study: comparison of amputation rate in venous and prosthetic grafts. Eur J Vasc Endovasc Surg. 2005;30(6):604-9. [pmid: 16098774].
Smeets L, Van Der Horn G, Gisbertz SS, et al. Does conversion of intended remote iliac artery endarterectomy alter the early and long-term outcome?. Vascular. 2005;13(6):336-42. [pmid: 16390651].
Solakovic E, Totic D, Solakovic S. Femoro-popliteal bypass above knee with saphenous vein vs synthetic graft. Bosn J Basic Med Sci. 2008;8(4):367-72. [pmid: 19125710].
Spiliopoulos S, Katsanos K, Karnabatidis D, et al. Cryoplasty versus conventional balloon angioplasty of the femoropopliteal artery in diabetic patients: long-term results from a prospective randomized single-center controlled trial. Cardiovasc Intervent Radiol. 2010;33(5):929-38. [pmid: 20574796].
Sultan S, Tawfick W, Hynes N. Cool excimer laser-assisted angioplasty vs tibial balloon angioplasty in management of infragenicular tibial arterial occlusion in critical lower limb ischemia TASC D. Vasc Dis Manage. 2011;8(11):E187-97.
Tetteroo E, Van Der Graaf Y, Bosch JL, et al. Randomised comparison of primary stent placement versus primary angioplasty followed by selective stent placement in patients with iliac-artery occlusive disease. Dutch Iliac Stent Trial Study Group. Lancet. 1998;351(9110):1153-9. [pmid: 9643685].
Tew G, Nawaz S, Zwierska I, et al. Limb-specific and cross-transfer effects of arm-crank exercise training in patients with symptomatic peripheral arterial disease. Clin Sci (Lond). 2009;117(12):405-13. [pmid: 19388883].
Thompson MM, Sayers RD, Reid A, et al. Quality of life following infragenicular bypass and lower limb amputation. Eur J Vasc Endovasc Surg. 1995;9(3):310-3. [pmid: 7620957].
Tielbeek AV, Vroegindeweij D, Buth J, et al. Comparison of balloon angioplasty and Simpson atherectomy for lesions in the femoropopliteal artery: angiographic and clinical results of a prospective randomized trial. J Vasc Interv Radiol. 1996;7(6):837-44. [pmid: 8951750].
Timaran CH, Stevens SL, Freeman MB, et al. External iliac and common iliac artery angioplasty and stenting in men and women. J Vasc Surg. 2001;34(3):440-6. [pmid: 11533595].
Tofigh AM, Warnier De, Wailly G, Rhissassi B. Comparing vein with collagen impregnated woven polyester prosthesis in above-knee femoropopliteal bypass grafting. Int J Surg. 2007;5(2):109-13. [pmid: 17448975].
Townley WA, Carrell TW, Jenkins MP, et al. Critical limb ischemia in the dialysis-dependent patient: infrainguinal vein bypass is justified. Vasc Endovascular Surg. 2006;40(5):362-6. [pmid: 17038569].
Treat-Jacobson D, Henly SJ, Bronas UG, et al. The pain trajectory during treadmill testing in peripheral artery disease. Nurs Res. 2011;60(3 Suppl):S38-49. [pmid: 21543960].
Troisi N, Dorigo W, Pratesi G, et al. Below-knee revascularization in patients with critical limb ischemia: long-term comparison of redo vs primary interventions. J Cardiovasc Surg (Torino). 2008;49(4):489-95. [pmid: 18665112].
Unni NM, Mandalam KR, Rao VR, et al. Balloon angioplasty of the femoro-popliteal segment: follow up results from southern India. Natl Med J India. 1995;8(3):105-13. [pmid: 7780349].
Urayama H, Ohtake H, Yokoi K, et al. Long-term results of endarterectomy, anatomic bypass and extraanatomic bypass for aortoiliac occlusive disease. Surg Today. 1998;28(2):151-5. [pmid: 9525003].
Van Det RJ, Vriens BH, Van Der Palen J, et al. Dacron or ePTFE for femoro-popliteal above-knee bypass grafting: short- and long-term results of a multicentre randomised trial. Eur J Vasc Endovasc Surg. 2009;37(4):457-63. [pmid: 19231253].
Volpe P, Conti B, Palazzo V, et al. Suprageniculate standard femoropopliteal bypass and popliteotibial angioplasty: An option for simultaneous combined open and endovascular treatment in limb salvage. Ital J Vasc Endovasc Surg. 2009;16(1):23-9.
Vroegindeweij D, Tielbeek AV, Buth J, et al. Directional atherectomy versus balloon angioplasty in segmental femoropopliteal artery disease: two-year follow-up with color-flow duplex scanning. J Vasc Surg. 1995;21(2):255-68. discussion 268-9. [pmid: 7853599].
Vroegindeweij D, Vos LD, Tielbeek AV, et al. Balloon angioplasty combined with primary stenting versus balloon angioplasty alone in femoropopliteal obstructions: A comparative randomized study. Cardiovasc Intervent Radiol. 1997;20(6):420-5. [pmid: 9354709].
Walker RD, Nawaz S, Wilkinson CH, et al. Influence of upper- and lower-limb exercise training on cardiovascular function and walking distances in patients with intermittent claudication. J Vasc Surg. 2000;31(4):662-9. [pmid: 10753273].
Walluscheck KP, Bierkandt S, Brandt M, et al. Infrainguinal ePTFE vascular graft with bioactive surface heparin bonding. First clinical results. J Cardiovasc Surg (Torino). 2005;46(4):425-30. [pmid: 16160689].
Wang E, Hoff J, Loe H, et al. Plantar flexion: an effective training for peripheral arterial disease. Eur J Appl Physiol. 2008;104(4):749-56. [pmid: 18726111].
Watelet J, Soury P, Menard JF, et al. Femoropopliteal bypass: in situ or reversed vein grafts? Ten-year results of a randomized prospective study. Ann Vasc Surg. 1997;11(5):510-9. [pmid: 9302064].
Wijesinghe LD, Beardsmore DM, Scott DJ. Polytetrafluoroethylene (PTFE) femorodistal grafts with a distal vein cuff for critical ischaemia. Eur J Vasc Endovasc Surg. 1998;15(5):449-53. [pmid: 9633503].
Wilson YG, Davies AH, Currie IC, et al. Angioscopically-assisted in situ saphenous vein bypass for infrainguinal revascularisation. Eur J Vasc Endovasc Surg. 1996;12(2):223-9. [pmid: 8760987].
Wolosker N, Nakano L, Rosoky RA, et al. Evaluation of walking capacity over time in 500 patients with intermittent claudication who underwent clinical treatment. Arch Intern Med. 2003;163(19):2296-300. [pmid: 14581248].
Yasa H, Cakir C, Tetik O, et al. Bypass grafting for infrapopliteal occlusive disease with poor distal flow on angiography. Anadolu Kardiyol Derg. 2008;8(6):444-8. [pmid: 19103541].
Yilmaz S, Sindel T, Yegin A, et al. Subintimal angioplasty of long superficial femoral artery occlusions. J Vasc Interv Radiol. 2003;14(8):997-1010. [pmid: 12902557].
Zdanowski Z, Albrechtsson U, Lundin A, et al. Percutaneous transluminal angioplasty with or without stenting for femoropopliteal occlusions? A randomized controlled study. Int Angiol. 1999;18(4):251-5. [pmid: 10811511].
Zukauskas G, Ulevicius H, Janusauskas E. An optimal inflow procedure for multi-segmental occlusive arterial disease: ilio-femoral versus aorto-bifemoral bypass. Cardiovasc Surg. 1998;6(3):250-5. [pmid: 9705096].
Zwierska I, Walker RD, Choksy SA, et al. Upper- vs lower-limb aerobic exercise rehabilitation in patients with symptomatic peripheral arterial disease: a randomized controlled trial. J Vasc Surg. 2005;42(6):1122-30. [pmid: 16376202].

## No outcomes of interest ≥30 days

Burdess A, Nimmo AF, Garden OJ, et al. Randomized controlled trial of dual antiplatelet therapy in patients undergoing surgery for critical limb ischemia. Ann Surg. 2010;252(1):37-42. [pmid: 20562608].