# Study Characteristics Tables

Table C-1 Study characteristics table for KQ 1: Effectiveness and safety of antiplatelet therapy for adults with peripheral artery disease

Table C-2 Study characteristics table for KQ 2: Effectiveness and safety of exercise, medications, and endovascular and surgical revascularization for intermittent claudication

Table C-3 Study characteristics table for KQ 3: Effectiveness and safety of endovascular and surgical revascularization for critical limb ischemia and mixed IC-CLI population

## References Cited in Appendix C

1 Belch J, MacCuish A, Campbell I, et al. The prevention of progression of arterial disease and diabetes (POPADAD) trial: factorial randomised placebo controlled trial of aspirin and antioxidants in patients with diabetes and asymptomatic peripheral arterial disease. BMJ. 2008;337:a1840. [pmid: 18927173].
2 Fowkes FG, Price JF, Stewart MC, et al. Aspirin for prevention of cardiovascular events in a general population screened for a low ankle brachial index: a randomized controlled trial. JAMA. 2010;303(9):841-8. [pmid: 20197530].
3 Anonymous. A randomised, blinded, trial of clopidogrel versus aspirin in patients at risk of ischaemic events (CAPRIE). Lancet. 1996;348(9038):1329-39. [pmid: 8918275].
4 Cacoub PP, Bhatt DL, Steg PG, et al. Patients with peripheral arterial disease in the CHARISMA trial. Eur Heart J. 2009;30(2):192-201. [pmid: 19136484].
5 Bhatt DL, Flather MD, Hacke W, et al. Patients with prior myocardial infarction, stroke, or symptomatic peripheral arterial disease in the CHARISMA trial. J Am Coll Cardiol. 2007;49(19):1982-8. [pmid: 17498584].
6 Bhatt DL, Fox KA, Hacke W, et al. Clopidogrel and aspirin versus aspirin alone for the prevention of atherothrombotic events. N Engl J Med. 2006;354(16):1706-17. [pmid: 16531616].
7 Berger PB, Bhatt DL, Fuster V, et al. Bleeding complications with dual antiplatelet therapy among patients with stable vascular disease or risk factors for vascular disease: results from the Clopidogrel for High Atherothrombotic Risk and Ischemic Stabilization, Management, and Avoidance (CHARISMA) trial. Circulation. 2010;121(23):2575-83. [pmid: 20516378].
8 Catalano M, Born G, Peto R. Prevention of serious vascular events by aspirin amongst patients with peripheral arterial disease: randomized, double-blind trial. J Intern Med. 2007;261(3):276-84. [pmid: 17305650].
9 Cassar K, Ford I, Greaves M, et al. Randomized clinical trial of the antiplatelet effects of aspirin-clopidogrel combination versus aspirin alone after lower limb angioplasty. Br J Surg. 2005;92(2):159-65. [pmid: 15609386].
10 Mahmood A, Sintler M, Edwards AT, et al. The efficacy of aspirin in patients undergoing infra-inguinal bypass and identification of high risk patients. Int Angiol. 2003;22(3):302-7. [pmid: 14612858].
11 Belch JJ, Dormandy J, Biasi GM, et al. Results of the randomized, placebo-controlled clopidogrel and acetylsalicylic acid in bypass surgery for peripheral arterial disease (CASPAR) trial. J Vasc Surg. 2010;52(4):825-33. 833 e1. 2. [pmid: 20678878].
12 Tepe G, Bantleon R, Brechtel K, et al. Management of peripheral arterial interventions with mono or dual antiplatelet therapy-the MIRROR study: a randomised and double-blinded clinical trial. Eur Radiol. 2012;22(9):1998-2006. [pmid: 22569995].
13 Horrocks M, Horrocks EH, Murphy P, et al. The effects of platelet inhibitors on platelet uptake and restenosis after femoral angioplasty. Int Angiol. 1997;(2):101-6. [pmid: 9257670].
14 Minar E, Ahmadi A, Koppensteiner R, et al. Comparison of effects of high-dose and low-dose aspirin on restenosis after femoropopliteal percutaneous transluminal angioplasty. Circulation. 1995;91(8):2167-73. [pmid: 7697845].
15 Beebe HG, Dawson DL, Cutler BS, et al. A new pharmacological treatment for intermittent claudication: results of a randomized, multicenter trial. Arch Intern Med. 1999;159(17):2041-50. [pmid: 10510990].
16 Belcaro G, Nicolaides AN, Griffin M, et al. Intermittent claudication in diabetics: treatment with exercise and pentoxifylline--a 6-month, controlled, randomized trial. Angiology. Suppl 1. 2002;53:S39-43. [pmid: 11865835].
17 Dawson DL, Cutler BS, Meissner MH, et al. Cilostazol has beneficial effects in treatment of intermittent claudication: results from a multicenter, randomized, prospective, double-blind trial. Circulation. 1998;98(7):678-86. [pmid: 9715861].
18 Dawson DL, Cutler BS, Hiatt WR, et al. A comparison of cilostazol and pentoxifylline for treating intermittent claudication. Am J Med. 2000;109(7):523-30. [pmid: 11063952].
19 De Sanctis MT, Cesarone MR, Belcaro G, et al. Treatment of intermittent claudication with pentoxifylline: a 12-month, randomized trial--walking distance and microcirculation. Angiology. Suppl 1. 2002;53:S7-12. [pmid: 11865838].
20 De Sanctis MT, Cesarone MR, Belcaro G, et al. Treatment of long-distance intermittent claudication with pentoxifylline: a 12-month, randomized trial. Angiology. Suppl 1. 2002;53:S13-7. [pmid: 11865829].
21 Cesarone MR, Belcaro G, Nicolaides AN, et al. Treatment of severe intermittent claudication with pentoxifylline: a 40-week, controlled, randomized trial. Angiology. Suppl 1. 2002;53:S1-5. [pmid: 11865828].
22 Hiatt WR, Money SR, Brass EP. Long-term safety of cilostazol in patients with peripheral artery disease: the CASTLE study (Cilostazol: A Study in Long-term Effects). J Vasc Surg. 2008;47(2):330-336. [pmid: 18155871].
23 Stone WM, Demaerschalk BM, Fowl RJ, et al. Type 3 phosphodiesterase inhibitors may be protective against cerebrovascular events in patients with claudication. J Stroke Cerebrovasc Dis. 2008;17(3):129-33. [pmid: 18436153].
24 Hobbs SD, Marshall T, Fegan C, et al. The effect of supervised exercise and cilostazol on coagulation and fibrinolysis in intermittent claudication: a randomized controlled trial. J Vasc Surg. 2007;45(1):65-70. discussion 70. [pmid: 17210383].
25 Money SR, Herd JA, Isaacsohn JL, et al. Effect of cilostazol on walking distances in patients with intermittent claudication caused by peripheral vascular disease. J Vasc Surg. 1998;27(2):267-74. discussion 274-5. [pmid: 9510281].
26 Soga Y, Yokoi H, Kawasaki T, et al. Efficacy of cilostazol after endovascular therapy for femoropopliteal artery disease in patients with intermittent claudication. J Am Coll Cardiol. 2009;53(1):48-53. [pmid: 19118724].
27 Strandness DE Jr, Dalman RL, Panian S, et al. Effect of cilostazol in patients with intermittent claudication: a randomized, double-blind, placebo-controlled study. Vasc Endovascular Surg. 2002;36(2):83-91. [pmid: 11951094].
28 Crowther RG, Spinks WL, Leicht AS, et al. Effects of a long-term exercise program on lower limb mobility, physiological responses, walking performance, and physical activity levels in patients with peripheral arterial disease. J Vasc Surg. 2008;47(2):303-9. [pmid: 18241753].
29 Gardner AW, Katzel LI, Sorkin JD, et al. Effects of long-term exercise rehabilitation on claudication distances in patients with peripheral arterial disease: a randomized controlled trial. J Cardiopulm Rehabil. 2002;22(3):192-8. [pmid: 12042688].
30 Gardner AW, Parker DE, Montgomery PS, et al. Efficacy of quantified home-based exercise and supervised exercise in patients with intermittent claudication: a randomized controlled trial. Circulation. 2011;123(5):491-8. [pmid: 21262997].
31 Gelin J, Jivegard L, Taft C, et al. Treatment efficacy of intermittent claudication by surgical intervention, supervised physical exercise training compared to no treatment in unselected randomised patients I: one year results of functional and physiological improvements. Eur J Vasc Endovasc Surg. 2001;22(2):107-13. [pmid: 11472042].
32 Taft C, Karlsson J, Gelin J, et al. Treatment efficacy of intermittent claudication by invasive therapy, supervised physical exercise training compared to no treatment in unselected randomised patients II: one-year results of health-related quality of life. Eur J Vasc Endovasc Surg. 2001;22(2):114-23. [pmid: 11472043].
33 Gibellini R, Fanello M, Bardile AF, et al. Exercise training in intermittent claudication. Int Angiol. 2000;19(1):8-13. [pmid: 10853679].
34 Hobbs SD, Marshall T, Fegan C, et al. The constitutive procoagulant and hypofibrinolytic state in patients with intermittent claudication due to infrainguinal disease significantly improves with percutaneous transluminal balloon angioplasty. J Vasc Surg. 2006;43(1):40-6. [pmid: 16414385].
35 Lee HL, Mehta T, Ray B, et al. A non-randomised controlled trial of the clinical and cost effectiveness of a Supervised Exercise Programme for claudication. Eur J Vasc Endovasc Surg. 2007;33(2):202-7. [pmid: 17142065].
36 Murphy TP, Cutlip DE, Regensteiner JG, et al. Supervised exercise versus primary stenting for claudication resulting from aortoiliac peripheral artery disease: six-month outcomes from the claudication: exercise versus endoluminal revascularization (CLEVER) study. Circulation. 2012;125(1):130-9. [pmid: 22090168].
37 Sugimoto I, Ohta T, Ishibashi H, et al. Conservative treatment for patients with intermittent claudication. Int Angiol. 2010;29(2 Suppl):55-60. [pmid: 20357750].
38 Treat-Jacobson D, Bronas UG, Leon AS. Efficacy of arm-ergometry versus treadmill exercise training to improve walking distance in patients with claudication. Vasc Med. 2009;14(3):203-13. [pmid: 19651669].
39 Bronas UG, Treat-Jacobson D, Leon AS. Comparison of the effect of upper body-ergometry aerobic training vs treadmill training on central cardiorespiratory improvement and walking distance in patients with claudication. J Vasc Surg. 2011;53(6):1557-64. [pmid: 21515017].
40 Tsai JC, Chan P, Wang CH, et al. The effects of exercise training on walking function and perception of health status in elderly patients with peripheral arterial occlusive disease. J Intern Med. 2002;252(5):448-55. [pmid: 12528763].
41 Feinglass J, McCarthy WJ, Slavensky R, et al. Functional status and walking ability after lower extremity bypass grafting or angioplasty for intermittent claudication: results from a prospective outcomes study. J Vasc Surg. 2000;31(1 Pt 1):93-103. [pmid: 10642712].
42 Giugliano G, Di Serafino L, Perrino C, et al. Effects of successful percutaneous lower extremity revascularization on cardiovascular outcome in patients with peripheral arterial disease. International Journal of Cardiology. 2012.
43 Koivunen K, Lukkarinen H. One-year prospective health-related quality-of-life outcomes in patients treated with conservative method, endovascular treatment or open surgery for symptomatic lower limb atherosclerotic disease. Eur J Cardiovasc Nurs. 2008;7(3):247-56. [pmid: 18221916].
44 Nylaende M, Abdelnoor M, Stranden E, et al. The Oslo balloon angioplasty versus conservative treatment study (OBACT)—The 2-years results of a single centre, prospective, randomised study in patients with intermittent claudication. Eur J Vasc Endovasc Surg. 2007;33(1):3-12. [pmid: 17055756].
45 Pell JP, Lee AJ. Impact of angioplasty and arterial reconstructive surgery on the quality of life of claudicants. The Scottish Vascular Audit Group. Scott Med J. 1997;42(2):47-8. [pmid: 9507581].
46 Whyman MR, Fowkes FG, Kerracher EM, et al. Is intermittent claudication improved by percutaneous transluminal angioplasty? A randomized controlled trial. J Vasc Surg. 1997;26(4):551-7. [pmid: 9357454].
47 Whyman MR, Fowkes FG, Kerracher EM, et al. Randomised controlled trial of percutaneous transluminal angioplasty for intermittent claudication. Eur J Vasc Endovasc Surg. 1996;12(2):167-72. [pmid: 8760978].
48 Mori E, Komori K, Kume M, et al. Comparison of the long-term results between surgical and conservative treatment in patients with intermittent claudication. Surgery. 2002;131(1 Suppl):S269-74. [pmid: 11821823].
49 Greenhalgh RM, Belch JJ, Brown LC, et al. The adjuvant benefit of angioplasty in patients with mild to moderate intermittent claudication (MIMIC) managed by supervised exercise, smoking cessation advice and best medical therapy: results from two randomised trials for stenotic femoropopliteal and aortoiliac arterial disease. Eur J Vasc Endovasc Surg. 2008;36(6):680-8. [pmid: 19022184].
50 Kruidenier LM, Nicolai SP, Rouwet EV, et al. Additional supervised exercise therapy after a percutaneous vascular intervention for peripheral arterial disease: a randomized clinical trial. J Vasc Interv Radiol. 2011;22(7):961-8. [pmid: 21571547].
51 Mazari FA, Khan JA, Carradice D, et al. Randomized clinical trial of percutaneous transluminal angioplasty, supervised exercise and combined treatment for intermittent claudication due to femoropopliteal arterial disease. Br J Surg. 2012;99(1):39-48. [pmid: 22021102].
52 Mazari FA, Gulati S, Rahman MN, et al. Early outcomes from a randomized, controlled trial of supervised exercise, angioplasty, and combined therapy in intermittent claudication. Ann Vasc Surg. 2010;24(1):69-79. [pmid: 19762206].
53 Nordanstig J, Gelin J, Hensater M, et al. Walking performance and health-related quality of life after surgical or endovascular invasive versus non-invasive treatment for intermittent claudication--a prospective randomised trial. Eur J Vasc Endovasc Surg. 2011;42(2):220-7. [pmid: 21397530].
54 Perkins JM, Collin J, Creasy TS, et al. Exercise training versus angioplasty for stable claudication. Long and medium term results of a prospective, randomised trial. Eur J Vasc Endovasc Surg. 1996;11(4):409-13. [pmid: 8846172].
55 Spronk S, Bosch JL, den Hoed PT, et al. Intermittent claudication: clinical effectiveness of endovascular revascularization versus supervised hospital-based exercise training--randomized controlled trial. Radiology. 2009;250(2):586-95. [pmid: 19188327].
56 Spronk S, Bosch JL, den Hoed PT, et al. Cost-effectiveness of endovascular revascularization compared to supervised hospital-based exercise training in patients with intermittent claudication: a randomized controlled trial. J Vasc Surg. 2008;48(6):1472-80. [pmid: 18771879].
57 Drozdz W, Panek J, Lejman W. Red cell deformability in patients with chronic atheromatous ischemia of the legs. Med Sci Monit. 2001;7(5):933-9. [pmid: 11535938].
58 Faglia E, Clerici G, Losa S, et al. Limb revascularization feasibility in diabetic patients with critical limb ischemia: results from a cohort of 344 consecutive unselected diabetic patients evaluated in 2009. Diabetes Res Clin Pract. 2012;95(3):364-71. [pmid: 22104261].
59 Kamiya C, Sakamoto S, Tamori Y, et al. Long-term outcome after percutaneous peripheral intervention vs medical treatment for patients with superficial femoral artery occlusive disease. Circ J. 2008;72(5):734-9. [pmid: 18441452].
60 Lawall H, Gorriahn H, Amendt K, et al. Long-term outcomes after medical and interventional therapy of critical limb ischemia. Eur J Intern Med. 2009;20(6):616-21. [pmid: 19782924].
61 Varty K, Nydahl S, Butterworth P, et al. Changes in the management of critical limb ischaemia. Br J Surg. 1996;83(7):953-6. [pmid: 8813785].
62 Varty K, Nydahl S, Nasim A, et al. Results of surgery and angioplasty for the treatment of chronic severe lower limb ischaemia. Eur J Vasc Endovasc Surg. 1998;16(2):159-63. [pmid: 9728437].
63 Adam DJ, Beard JD, Cleveland T, et al. Bypass versus angioplasty in severe ischaemia of the leg (BASIL): multicentre, randomised controlled trial. Lancet. 2005;366(9501):1925-34. [pmid: 16325694].
64 Bradbury AW, Adam DJ, Bell J, et al. Bypass versus Angioplasty in Severe Ischaemia of the Leg (BASIL) trial: A survival prediction model to facilitate clinical decision making. J Vasc Surg. 2010;51(5 Suppl):52S-68S. [pmid: 20435262].
65 Bradbury AW, Adam DJ, Bell J, et al. Bypass versus Angioplasty in Severe Ischaemia of the Leg (BASIL) trial: A description of the severity and extent of disease using the Bollinger angiogram scoring method and the TransAtlantic Inter-Society Consensus II classification. J Vasc Surg. 2010;51(5 Suppl):32S-42S. [pmid: 20435260].
66 Bradbury AW, Adam DJ, Bell J, et al. Bypass versus Angioplasty in Severe Ischaemia of the Leg (BASIL) trial: An intention-to-treat analysis of amputation-free and overall survival in patients randomized to a bypass surgery-first or a balloon angioplasty-first revascularization strategy. J Vasc Surg. 2010;51(5 Suppl):5S-17S. [pmid: 20435258].
67 Bradbury AW, Adam DJ, Bell J, et al. Bypass versus Angioplasty in Severe Ischaemia of the Leg (BASIL) trial: Analysis of amputation free and overall survival by treatment received. J Vasc Surg. 2010;51(5 Suppl):18S-31S. [pmid: 20435259].
68 Bradbury AW, Adam DJ, Bell J, et al. Multicentre randomised controlled trial of the clinical and cost-effectiveness of a bypass-surgery-first versus a balloon-angioplasty-first revascularisation strategy for severe limb ischaemia due to infrainguinal disease. The Bypass versus Angioplasty in Severe Ischaemia of the Leg (BASIL) trial. Health Technol Assess. 2010;14(14):1-210. iii. iv. [pmid: 20307380].
69 Forbes JF, Adam DJ, Bell J, et al. Bypass versus Angioplasty in Severe Ischaemia of the Leg (BASIL) trial: Health-related quality of life outcomes, resource utilization, and cost-effectiveness analysis. J Vasc Surg. 2010;51(5 Suppl):43S-51S. [pmid: 20435261].
70 Ah Chong AK, Tan CB, Wong MW, et al. Bypass surgery or percutaneous transluminal angioplasty to treat critical lower limb ischaemia due to infrainguinal arterial occlusive disease?. Hong Kong Med J. 2009;15(4):249-54. [pmid: 19652230].
71 Dorigo W, Pulli R, Marek J, et al. A comparison between open and endovascular repair in the treatment of critical limb ischemia. Ital J Vasc Endovasc Surg. 2009;16(1):17-22.
72 Dosluoglu HH, Lall P, Harris LM, et al. Long-term limb salvage and survival after endovascular and open revascularization for critical limb ischemia after adoption of endovascular-first approach by vascular surgeons. Journal of Vascular Surgery. 2012.
73 Dosluoglu HH, Lall P, Cherr GS, et al. Role of simple and complex hybrid revascularization procedures for symptomatic lower extremity occlusive disease. J Vasc Surg. 2010;51(6):1425-1435 e1. [pmid: 20488323].
74 Hoshino J, Fujimoto Y, Naruse Y, et al. Characteristics of revascularization treatment for arteriosclerosis obliterans in patients with and without hemodialysis. Circ J. 2010;74(11):2426-33. [pmid: 20938099].
75 Hynes N, Akhtar Y, Manning B, et al. Subintimal angioplasty as a primary modality in the management of critical limb ischemia: comparison to bypass grafting for aortoiliac and femoropopliteal occlusive disease. J Endovasc Ther. 2004;11(4):460-71. [pmid: 15298498].
76 Janne d'Othee B, Morris MF, Powell RJ, et al. Cost determinants of percutaneous and surgical interventions for treatment of intermittent claudication from the perspective of the hospital. Cardiovasc Intervent Radiol. 2008;31(1):56-65. [pmid: 17973158].
77 Jerabek J, Dvorak M, Vojtisek B. Results of therapy of lower extremity ischemic disease by angiosurgery and radiointervention (PTA) methods. Bratisl Lek Listy. 2003;104(10):314-6. [pmid: 15055731].
78 Johnson BF, Singh S, Evans L, et al. A prospective study of the effect of limb-threatening ischaemia and its surgical treatment on the quality of life. Eur J Vasc Endovasc Surg. 1997;13(3):306-14. [pmid: 9129605].
79 Kashyap VS, Pavkov ML, Bena JF, et al. The management of severe aortoiliac occlusive disease: endovascular therapy rivals open reconstruction. J Vasc Surg. 2008;48(6):1451-7. 1457 e1. 3. [pmid: 18804943].
80 Khan MU, Lall P, Harris LM, et al. Predictors of limb loss despite a patent endovascular-treated arterial segment. J Vasc Surg. 2009;49(6):1440-5. discussion 1445-6. [pmid: 19497503].
81 Korhonen M, Biancari F, Soderstrom M, et al. Femoropopliteal balloon angioplasty vs. bypass surgery for CLI: a propensity score analysis. Eur J Vasc Endovasc Surg. 2011;41(3):378-84. [pmid: 21195637].
82 Kudo T, Chandra FA, Kwun WH, et al. Changing pattern of surgical revascularization for critical limb ischemia over 12 years: endovascular vs. open bypass surgery. J Vasc Surg. 2006;44(2):304-13. [pmid: 16890859].
83 Laurila J, Brommels M, Standertskjold-Nordenstam CG, et al. Cost-effectiveness of Percutaneous Transluminal Angioplasty (PTA) Versus Vascular Surgery in Limb-threatening Ischaemia. Int J Angiol. 2000;9(4):214-219. [pmid: 11062310].
84 Lepantalo M, Laurila K, Roth WD, et al. PTFE bypass or thrupass for superficial femoral artery occlusion? A randomised controlled trial. Eur J Vasc Endovasc Surg. 2009;37(5):578-84. [pmid: 19231250].
85 Loor G, Skelly CL, Wahlgren CM, et al. Is atherectomy the best first-line therapy for limb salvage in patients with critical limb ischemia?. Vasc Endovascular Surg. 2009;43(6):542-50. [pmid: 19640919].
86 McQuade K, Gable D, Hohman S, et al. Randomized comparison of ePTFE/nitinol self-expanding stent graft vs prosthetic femoral-popliteal bypass in the treatment of superficial femoral artery occlusive disease. J Vasc Surg. 2009;49(1):109-15. 116 e1. 9. discussion 116. [pmid: 19028055].
87 McQuade K, Gable D, Pearl G, et al. Four-year randomized prospective comparison of percutaneous ePTFE/nitinol self-expanding stent graft versus prosthetic femoral-popliteal bypass in the treatment of superficial femoral artery occlusive disease. J Vasc Surg. 2010;52(3):584-90. discussion 590-1, 591 e1-591 e7. [pmid: 20598480].
88 Kedora J, Hohmann S, Garrett W, et al. Randomized comparison of percutaneous Viabahn stent grafts vs prosthetic femoral-popliteal bypass in the treatment of superficial femoral arterial occlusive disease. J Vasc Surg. 2007;45(1):10-6. discussion 16. [pmid: 17126520].
89 Rossi E, Citterio F, Castagneto M, et al. Safety of endovascular treatment in high-cardiac-risk patients with limb-threatening ischemia. Angiology. 1998;49(6):435-40. [pmid: 9631888].
90 Sachs T, Pomposelli F, Hamdan A, et al. Trends in the national outcomes and costs for claudication and limb threatening ischemia: Angioplasty vs bypass graft. J Vasc Surg. 2011;54(4):1021-1031 e1. [pmid: 21880457].
91 Soderstrom MI, Arvela EM, Korhonen M, et al. Infrapopliteal percutaneous transluminal angioplasty versus bypass surgery as first-line strategies in critical leg ischemia: a propensity score analysis. Ann Surg. 2010;252(5):765-73. [pmid: 21037432].
92 Stoner MC, Defreitas DJ, Manwaring MM, et al. Cost per day of patency: understanding the impact of patency and reintervention in a sustainable model of healthcare. J Vasc Surg. 2008;48(6):1489-96. [pmid: 18829227].
93 Sultan S, Hynes N. Five-year Irish trial of CLI patients with TASC II type C/D lesions undergoing subintimal angioplasty or bypass surgery based on plaque echolucency. J Endovasc Ther. 2009;16(3):270-83. [pmid: 19642779].
94 Sultan S, Hynes N. Mid-term results of subintimal angioplasty for critical limb ischemia 5-year outcomes. Vasc Dis Manage. 2011;8(9):E155-E163.
95 Taylor SM, Kalbaugh CA, Blackhurst DW, et al. Postoperative outcomes according to preoperative medical and functional status after infrainguinal revascularization for critical limb ischemia in patients 80 years and older. Am Surg. 2005;71(8):640-5. discussion 645-6. [pmid: 16217945].
96 Taylor SM, Kalbaugh CA, Blackhurst DW, et al. Determinants of functional outcome after revascularization for critical limb ischemia: an analysis of 1000 consecutive vascular interventions. J Vasc Surg. 2006;44(4):747-55. discussion 755-6. [pmid: 16926083].
97 Taylor SM, York JW, Cull DL, et al. Clinical success using patient-oriented outcome measures after lower extremity bypass and endovascular intervention for ischemic tissue loss. J Vasc Surg. 2009;50(3):534-41. discussion 541. [pmid: 19592193].
98 Timaran CH, Ohki T, Gargiulo NJ 3rd, et al. Iliac artery stenting in patients with poor distal runoff: Influence of concomitant infrainguinal arterial reconstruction. J Vasc Surg. 2003;38(3):479-84. discussion 484-5. [pmid: 12947261].
99 Timaran CH, Prault TL, Stevens SL, et al. Iliac artery stenting versus surgical reconstruction for TASC (TransAtlantic Inter-Society Consensus) type B and type C iliac lesions. J Vasc Surg. 2003;38(2):272-8. [pmid: 12891108].
100 Varela C, Acin F, De Haro J, et al. Influence of surgical or endovascular distal revascularization of the lower limbs on ischemic ulcer healing. J Cardiovasc Surg (Torino). 2011;52(3):381-9. [pmid: 21577193].
101 Venermo M, Biancari F, Arvela E, et al. The role of chronic kidney disease as a predictor of outcome after revascularisation of the ulcerated diabetic foot. Diabetologia. 2011. [pmid: 21845468].
102 Whatling PJ, Gibson M, Torrie EP, et al. Iliac occlusions: stenting or crossover grafting? An examination of patency and cost. Eur J Vasc Endovasc Surg. 2000;20(1):36-40. [pmid: 10906295].
103 Wolfle KD, Bruijnen H, Reeps C, et al. Tibioperoneal arterial lesions and critical foot ischaemia: successful management by the use of short vein grafts and percutaneous transluminal angioplasty. Vasa. 2000;29(3):207-14. [pmid: 11037720].
104 Zdanowski Z, Troeng T, Norgren L. Outcome and influence of age after infrainguinal revascularisation in critical limb ischaemia. The Swedish Vascular Registry. Eur J Vasc Endovasc Surg. 1998;16(2):137-41. [pmid: 9728433].