# Data Abstraction Elements

Study Characteristics
- Study name and acronym
- Other articles used in this abstraction
- Study dates
  ○ Date enrollment started (MM and YYYY)
  ○ Date enrollment ended (MM and YYYY)
  ○ Length of Followup (months or years)
- Enrollment source: Primary care, Cardiology, Radiology, Surgery, NR/NA
- Enrollment approach: consecutive patients, convenience sample, other (specify), unclear/not reported
  ○ Number of subjects screened/approached for study participation
  ○ Number eligible for study
  ○ Number randomized
  ○ Number completing followup
  ○ Number included in primary outcome analysis
- Study sites: Single center, Multicenter, Not reported/Unclear
  ○ Geographic location
    ■ If single center, enter City and State (if US) or City and Country (if outside US).
    ■ If multicenter, enter number of sites. Enter NR if not reported.
    ■ If multicenter, specify applicable geographic regions: US, Canada, UK, Europe, S. America, C. America, Asia, Africa, Australia/NZ, Not reported/Unclear, Other (specify)
- Funding source: Government, Private foundation, Nonprofit Organization, Industry, Not reported, Other (specify)
- Setting: Academic centers, Community hospitals, Outpatient, VA, Not reported/unclear, Other (specify)
- Inclusion and exclusion criteria; Copy/paste criteria as reported in the article.
- Symptom status of population studied: Asymptomatic, Intermittent claudication, Atypical claudication, Critical limb ischemia
- To which key questions and subquestions does this study apply?
  ○ KQ1: KQ1a, KQ1b, KQ1c
  ○ KQ2: KQ2a, KQ2b, KQ2c
  ○ KQ3: KQ3a, KQ3b, KQ3c
- Subgroup Analysis: Yes/No
- Comments (if needed)

Baseline Characteristics
- Number of Subjects
  ○ Total Population and Treatment Arms 1, 2, 3, 4
    ■ N
      - Total
      - Female
      - Male
    ■ Percentage
      - Female
      - Male
- Total Population – Age in years
  ○ Total Population and Treatment Arms 1, 2, 3, 4
    ■ Mean
    ■ SD
    ■ SE
    ■ Median
    ■ IQR
- Ethnicity
  ○ Total N and Percentage of Population
    ■ Hispanic or Latino
    ■ Not Hispanic or Latino
- Race
  ○ Total N and Percentage of Population
    ■ Black/African American
    ■ American Indian or Alaska Native
    ■ Asian
    ■ Native Hawaiian or other Pacific Islander
    ■ White
    ■ Multiracial
    ■ Other (specify)
- Baseline Characteristics
  ○ Total Population and Treatment Arms 1, 2, 3, 4
    ■ Diabetes (NR)
    ■ Tobacco use (NR)
    ■ Prior MI (NR)
    ■ Known CAD (NR)
    ■ Hyperlipidemia (NR)
    ■ Prior PCI (NR)
    ■ Prior CABG (NR)
    ■ Heart failure (NR)
    ■ Chronic kidney disease (NR)
    ■ Obesity (NR) – Define
    ■ Prior stroke (NR)
    ■ Prior TIA (NR)
    ■ Prior stroke or TIA (NR)
    ■ Prior carotid surgery (NR)
    ■ Claudication (NR)
    ■ Peripheral vascular disease (NR)
    ■ Prior lower extremity vascular surgery (NR)
    ■ Ankle brachial index (NR)
      - Mean/Median
      - SD/SE/IQR
    ■ Fontaine classification
      - Stage I
      - Stage IIa
      - Stage IIb
      - Stage 3
      - Stage 4
    ■ Rutherford classification
      - Stage 0
      - Stage 1
      - Stage 2
      - Stage 3
      - Stage 4
      - Stage 5
      - Stage 6
    ■ TASC II classification
      - A
      - B
      - C
      - D
      - A/B
      - C/D
    ■ Runoff vessels
      - Mean/Median
      - SD/SE/IQR
    ■ Runoff vessels (N)
      - 1
      - 2
      - 3
- Presentation
  ○ Total Population and Treatment Arms 1, 2, 3, 4
    ■ Asymptomatic (NR/NA)
    ■ Atypical leg pain (NR/NA)
    ■ Intermittent claudication (NR/NA)
    ■ Critical limb ischemia (NR/NA)
    ■ Mixed (specify) (NR/NA)
- Other socioeconomic factors: Yes/No
  ○ If yes: Specify the factor(s) and categories/units
  ○ If yes: Enter the characteristics as reported (e.g. range, mean and standard deviation, etc.)
- Comments (if needed)

Intervention Characteristics
- Briefly indicate which population/intervention combination is reflected by the data abstracted
  ○ Treatment Arms 1, 2, 3, 4
    ■ Population
      - Asymptomatic patients
      - Symptomatic patients with atypical leg symptoms
      - Patients with intermittent claudication
      - Patients with critical limb ischemia
      - Other (specify)
      - NR/NA
    ■ Intervention
      - Aspirin or antiplatelet agents
      - Cilostazol or pentoxifylline
      - Exercise training
      - Endovascular intervention
      - Surgical revascularization
      - Control/placebo
      - Other
      - NR/NA
- Intervention Characteristics: Describe the intervention received by patients in Treatment Arm 1, Treatment Arm 2, Treatment Arm 3, and Treatment Arm 4 (if applicable)
- Cointerventions
  ○ Acetylsalicylic acid (ASA); Additional antiplatelet agents (e.g. clopidogrel, prasugrel, ticagrelor); Antithrombin drugs (e.g. LMWH, unfractionated heparin, bivalirudin); Glycoprotein IIb/IIIa inhibitors; Thrombolytic/fibrinolytic drugs; Statins/lipid-lowering drugs; Beta-blockers; ACEIs/ARBs; Calcium channel blockers; Nitrates; Other (specify); NR/NA
- Medical Therapy Intervention(s)
  ○ Treatment Arm 1, 2, 3, 4 (NA)
    ■ Clopidogrel
      - Yes/No
      - Loading dose
      - Maintenance dose
      - Timing
      - Duration of treatment
    ■ Prasugrel
      - Yes/No
      - Loading dose
      - Maintenance dose
      - Timing
      - Duration of treatment
    ■ Ticagrelor
      - Yes/No
      - Loading dose
      - Maintenance dose
      - Timing
      - Duration of treatment
    ■ Cilostazol
      - Yes/No
      - Loading dose
      - Maintenance dose
      - Timing
      - Duration of treatment
    ■ Pentoxifylline
      - Yes/No
      - Loading dose
      - Maintenance dose
      - Timing
      - Duration of treatment
    ■ Aspirin
      - Yes/No
      - Loading dose
      - Maintenance dose
      - Timing
      - Duration of treatment
    ■ Glycoprotein IIb/IIIa (abciximab, eptifibatide, tirofiban)
      - Yes/No
      - Loading dose
      - Maintenance dose
      - Timing
      - Duration of treatment
    ■ Dipyridamole
      - Yes/No
      - Loading dose
      - Maintenance dose
      - Timing
      - Duration of treatment
    ■ Other #1, #2, #3 (specify)
      - Yes/No
      - Loading dose
      - Maintenance dose
      - Timing
      - Duration of treatment
- Exercise Therapy
  ○ Treatment Arm 1, 2, 3, 4
    ■ Exercise therapy type
      - Walking
      - Strength
      - Combined
      - Other
      - NR/NA
    ■ Exercise therapy duration
    ■ Protocol used
    ■ Supervision status
      - Supervised
      - Home
      - NR/NA
- Endovascular Revascularization Procedural Characteristics
  ○ Treatment Arm 1, 2, 3, 4
    ■ Complete revascularization achieved
    ■ Vessels treated (mean)
      - Mean/median
      - SD/SE/IQR
      - 1
      - 2
      - Unclear/Not specified
    ■ Interventional approach
      - Balloon
        ○ N or %
        ○ Type
          ■ Drug coated
          ■ Cutting
          ■ Cryoplasty
          ■ Standard
          ■ Other (specify)
      - Atherectomy
        ○ N or %
        ○ Type
          ■ Laser
          ■ Orbital
          ■ Rotational
          ■ Directional
          ■ Other (specify)
      - Stents
        ○ N or %
        ○ Type
          ■ Drug-eluting
          ■ Self-expandable open cell
          ■ Balloon expandable open cell
          ■ Closed cell (covered)
          ■ Other (specify)
          ■ NR
    ■ Stents used (mean)
      - Mean/median
      - SD/SE/IQR
      - 0
      - 1
      - 2
      - More than 2
      - Unclear/not specified
- Surgical Revascularization Procedural Characteristics
  ○ Treatment Arm 1, 2, 3, 4
    ■ Type of surgery
      - Axillofem or axillo bifem
      - Aortofem or aorto bifem
      - Fem-fem
      - Fem-pop
      - Fem-distal
      - Other (specify)
    ■ Type of grafts
      - Vein (native)
      - Synthetic
      - Composite
      - Cadaveric
    ■ Grafts used (mean)
      - Mean/median
      - SD/SE/IQR
      - 0
      - 1
      - 2
      - Greater than 2

Individual Outcomes
- Select the outcome reported: Total mortality, Cardiovascular mortality, Nonfatal myocardial infarction, Stroke, Repeat revascularization, Hospitalization, Length of hospital stay, Discharge status, Cost of hospital stay, Bleeding, Quality of life, Adverse drug reactions, Vessel patency, Wound healing, Pain, Major Amputation, Minor Amputation, Contrast nephropathy, Radiation, Infection, Exercise-related harms, Periprocedural complications, Maximal Walking distance, Peak Walking Time, Mean or 6-minute walking time, Claudication onset time, Absolute claudication distance, Mean claudication distance, Other 1, 2, 3, 4
  ○ Additional/alternate outcome name (if applicable)
  ○ Authors' definition of outcome (if applicable)
  ○ Was the post-procedure success rate measured? Yes/No/Unknown
    ■ If yes: Post-procedure success rate
  ○ Was the outcome reported at the patient level or limb level? Patient level/limb level/Other (specify)/(NR/NA)
  ○ Complete tables (1-5) to provide data for this outcome/time point(s).
    ■ Timing of the outcome data reported in the table: Short term ≤ 30 days/Intermediate term > 30 days and ≤ 1 year/Long-term > 1 year
      - If short term: In-hospital/30 days/Other (specify)
      - If intermediate term: 6 weeks/6 months/1 year/Other (specify)
      - If long term: 2 years/3 years/4 years/5 years/Other (specify)
    ■ Indicate whether/how the results reported were adjusted (check all that apply): Results are not adjusted, Age, Sex, Race/ethnicity, Comorbidity(ies) (specify), Bodyweight/BMI, Risk factors (smoking), PAD classification, Anatomy-specific factor (disease burden, location/pattern of stenosis, degree of calcification, # of below knee vessel runoff), Hospital characteristics (patient volume, setting, guideline-based treatment protocol), Other (specify all)
    ■ For each reported group (Antiplatelet therapy, Exercise therapy, Endovascular revascularization, Surgical revascularization, Medication, Other, NR/NA) record the following:
      - N for Analysis
      - Result
        ○ Mean
        ○ Median
        ○ Number of patients with outcome
        ○ % of patients with outcome
        ○ Relative risk
        ○ Relative hazard
        ○ Odds ratio
        ○ Risk difference
        ○ Other (specify)
      - Variability
        ○ Standard Error (SE)
        ○ Standard Deviation (SD)
        ○ Other (specify)
      - Confidence Interval (CI) or Interquartile Range (IQR)
        ○ 95% CI
          ■ LL (25% if IQR)
          ■ UL (75% if IQR)
        ○ Other %CI
          ■ LL (25% if IQR)
          ■ UL (75% if IQR)
        ○ IQR
          ■ LL (25% if IQR)
          ■ UL (75% if IQR)
      - p-value between tx groups
      - Reference group (for comparisons between tx groups)
        ○ Treatment Arm 1, Treatment Arm 2, Treatment Arm 3, Treatment Arm 4, No Comparison
  ○ Comments (if needed)

Composite Outcomes
- Composite outcome data #1, #2, #3, #4
  ○ Is this a Primary or Secondary composite outcome? Primary/Secondary/Unclear
  ○ Indicate the components that make up this composite outcome (check all that apply): Total mortality, Cardiovascular mortality, Nonfatal myocardial infarction, Stroke, Repeat revascularization, Hospitalization, Length of hospital stay, Discharge status, Cost of hospital stay, Bleeding, Quality of life, Adverse drug reactions, Vessel patency, Wound healing, Pain, Major Amputation, Minor Amputation, Contrast nephropathy, Radiation, Infection, Exercise-related harms, Periprocedural complications, Maximal Walking distance, Peak Walking Time, Mean or 6-minute walking time, Claudication onset time, Absolute claudication distance, Mean claudication distance, Other 1, 2, 3, 4
  ○ Was the outcome reported at the patient level or limb level?
  ○ Complete tables (1-5) to provide data for this outcome/time point(s).
    ■ Timing of the outcome data reported in the table: Short term ≤ 30 days/Intermediate term > 30 days and ≤ 1 year/Long-term > 1 year
      - If short term: In-hospital/30 days/Other (specify)
      - If intermediate term: 6 weeks/6 months/1 year/Other (specify)
      - If long term: 2 years/3 years/4 years/5 years/Other (specify)
    ■ Indicate whether/how the results reported were adjusted (check all that apply): Results are not adjusted, Age, Sex, Race/ethnicity, Comorbidity(ies) (specify), Bodyweight/BMI, Risk factors (smoking), PAD classification, Anatomy-specific factor (disease burden, location/pattern of stenosis, degree of calcification, # of below knee vessel runoff), Hospital characteristics (patient volume, setting, guideline-based treatment protocol), Other (specify all)
    ■ For each reported group (Antiplatelet therapy, Exercise therapy, Endovascular revascularization, Surgical revascularization, Medication, Other, NR/NA) record the following:
      - N for Analysis
      - Result
        ○ Mean
        ○ Median
        ○ Number of patients with outcome
        ○ % of patients with outcome
        ○ Relative risk
        ○ Relative hazard
        ○ Odds ratio
        ○ Risk difference
        ○ Other (specify)
      - Variability
        ○ Standard Error (SE)
        ○ Standard Deviation (SD)
        ○ Other (specify)
      - Confidence Interval (CI) or Interquartile Range (IQR)
        ○ 95% CI
          ■ LL (25% if IQR)
          ■ UL (75% if IQR)
        ○ Other %CI
          ■ LL (25% if IQR)
          ■ UL (75% if IQR)
        ○ IQR
          ■ LL (25% if IQR)
          ■ UL (75% if IQR)
      - p-value between tx groups
      - Reference group (for comparisons between tx groups)
        ○ Treatment Arm 1, Treatment Arm 2, Treatment Arm 3, Treatment Arm 4, No Comparison
  ○ Comments (if needed)

Quality Assessment
- Was this study randomized? Yes/No
  ○ If yes:
    ■ Were study subjects randomized? Yes/No/Unclear
    ■ Was the randomization process described? Yes/No/Unclear
    ■ Was the outcome assessor blinded to study assignment? Yes/No/Unclear
    ■ Were patients blinded to study intervention? Yes/No/Unclear
    ■ Were results adjusted for clustering? Yes/No/Unclear
    ■ Were measures of outcomes based on validated procedures or instruments? Yes/No/Unclear
    ■ Conducted an intent to treat analysis? Yes/No/Unclear
    ■ Were all outcomes reported (i.e. was there evidence of selective outcome reporting)? Yes/No/Unclear
    ■ Were incomplete data adequately addressed (i.e. no systematic difference between groups in withdrawals/loss to followup AND no high drop-out or loss to followup rate [>30%])? Yes/No/Unclear
    ■ Was there adequate power (either based on pre-study or post-hoc power calculations [80% power for primary outcome])? Yes/No/Unclear
    ■ Were systematic differences observed in baseline characteristics and prognostic factors across the groups compared? Yes/No/Unclear
    ■ Were comparable groups maintained (Includes crossovers, adherence, and contamination. Consider issues of crossover [e.g. from one intervention to another], adherence [major differences in adherence to the interventions being compared], contamination [e.g. some members of control group get intervention], or other systematic difference in care that was provided.)? Yes/No/Unclear
    ■ Was there absence of potential important conflict-of-interest (Focus on financial conflicts with for-profit capacities; government or non-profit funding = ‘yes’)? Yes/No/Unclear
    ■ Overall Study Rating:
      - A “Good” study has the least bias, and results are considered valid. A good study has a clear description of the population, setting, interventions, and comparison groups; uses a valid approach to allocate patients to alternative treatments; has a low dropout rate; and uses appropriate means to prevent bias, measure outcomes, and analyze and report results.
      - A “Fair” study is susceptible to some bias but probably not enough to invalidate the results. The study may be missing information, making it difficult to assess limitations and potential problems. As the fair-quality category is broad, studies with this rating vary in their strengths and weaknesses. The results of some fair-quality studies are possibly valid, while others are probably valid.
      - A “Poor” rating indicates significant bias that may invalidate the results. These studies have serious errors in design, analysis, or reporting; have large amounts of missing information; or have discrepancies in reporting. The results of a poor-quality study are at least as likely to reflect flaws in the study design as to indicate true differences between the compared interventions.
  ○ If no:
    ■ Basic Design
      - Is the study design prospective, retrospective, or mixed [Prospective design requires that the investigator plans a study before any data are collected. Mixed design includes case-control or cohort studies in which one group is studied prospectively and the other retrospectively.]? Prospective/Mixed/Retrospective/Cannot determine
    ■ Selection Bias
      - Inclusion/Exclusion Criteria
        ○ Are the inclusion/exclusion criteria clearly stated (does not require the reader to infer)? Yes/Partially (only some criteria stated or some criteria not stated clearly)/No
        ○ Did the study apply inclusion/exclusion criteria uniformly to all comparison groups? Yes/Partially (only some criteria stated or some criteria not stated clearly)/No/NA (study does not include comparison groups)
      - Recruitment
        ○ Did the strategy for recruiting participants into the study differ across study groups? Yes/No/Cannot determine/NA (retrospective study design)
      - Baseline characteristics similar or appropriate adjusted analysis
        ○ Are key characteristics of study participants similar between intervention and control groups? If not similar, did the analysis appropriately adjust for important differences? Yes (similar or appropriate adjusted analysis)/Partially (only some characteristics described or some characteristics not clearly described; analysis adjusted for some)/No (important baseline differences; unadjusted analysis)/Insufficient reporting to be able to determine
      - Comparison Group
        ○ Is the selection of the comparison group appropriate? Yes/No/Cannot determine (no description of the derivation of the comparison cohort)/NA (study does not include a comparison cohort – case series, one-arm study)
    ■ Performance Bias
      - Intervention implementation
        ○ What is the level of detail in describing the intervention or exposure? High (very clear, all PI-required details provided)/Medium (somewhat clear, majoring of PI-required details provided)/Low (unclear, many PI-required details missing)
      - Concurrent/concomitant interventions
        ○ Did researchers isolate the impact from a concurrent intervention or unintended exposure that might bias the results, e.g., through multivariate analysis, stratification, or subgroup analysis? Yes/Partially (only some concurrent interventions eliminated)/Not described
    ■ Attrition Bias
      - Equality of length of followup for participants
        ○ In cohort studies, is the length of followup different between groups? Yes/No or cannot determine/not applicable (cross-sectional or only one group followed over time)
      - Completeness of followup
        ○ Was there a high rate of differential or overall attrition? Yes/No/Cannot determine
      - Attrition affecting participant composition
        ○ Did attrition result in a difference in group characteristics between baseline and followup? Yes/No/Cannot determine
      - Any attempt to balance
        ○ Any attempt to balance the allocation between groups (e.g. through stratification, matching, propensity scores)? Yes/No/Cannot determine
      - Intention-to-treat analysis
        ○ Is the analysis conducted on an intention-to-treat (ITT) basis, that is, the intervention allocation status rather than the actual intervention received? Yes/No/Cannot determine/NA (retrospective study)
    ■ Detection Bias
      - Source of information re: outcomes
        ○ Are [underlined: procedural outcomes] (e.g. vessel patency, wound healing) assessed using valid and reliable measure and implemented consistently across all study participants? Yes/No/Cannot determine (measurement approach not reported)
        ○ Are [underlined: event outcomes] (e.g. mortality, MI, CVA, repeat revascularization, amputation) assessed using valid and reliable measures and implemented consistently across all study participants? Yes/No/Cannot determine (measurement approach not reported)
        ○ Are [underlined: patient-reported outcomes] (e.g. pain scores, quality of life) assessed using valid and reliable measures implemented consistently across all study participants? Yes/No/Cannot determine (measurement approach not reported)
        ○ Are [underlined: functional capacity outcomes] (e.g. walking time/distance, claudication time/distance) assessed using valid and reliable measures, implemented consistently across all study participants? Yes/No/Cannot determine (measurement approach not reported)
    ■ Reporting Bias
      - Are any important primary outcomes missing from the results? Yes/No/Cannot determine/Primary outcomes not pre-specified
    ■ Other risk of bias issues
      - Are the statistical methods used to assess the primary outcomes appropriate to the data? Yes/Partially/No/Cannot determine
      - Power and sample size
        ○ Did the authors report conducting a power analysis or some other basis for determining the adequacy of study group sizes for the primary outcome(s) being abstracted? Yes/No/NA (primary outcomes statistically significant)
    ■ Overall Rating of the study
      - A “Low Risk of Bias” study has the least bias, and results are considered valid. A good study has a clear description of the population, setting, interventions, and comparison groups; uses recruitment and eligibility criteria that minimizes selection bias; has a low attrition rate; and uses appropriate means to prevent bias, measure outcomes, and analyze and report results. These studies will meet the majority of items in each domain.
      - A “Moderate Risk of Bias” study is susceptible to some bias but probably not enough to invalidate the results. The study may be missing information, making it difficult to assess limitations and potential problems. As the fair-quality category is broad, studies with this rating vary in their strengths and weaknesses. The results of some fair-quality studies are possibly valid, while others are probably valid. These studies will meet the majority of items in most but not all domains.
      - A “High Risk of Bias” rating indicates significant bias that may invalidate the results. These studies have serious errors in design, analysis, or reporting; have large amounts of missing information; or have discrepancies in reporting. The results of a poor-quality study are at least as likely to reflect flaws in the study design as to indicate true differences between the compared interventions.