# Exact Search Strings

## PubMed^®^ Search Strategy (August 13, 2012)

Table A-1 KQ 1: Effectiveness and safety of aspirin and antiplatelets for patients with peripheral artery disease

Set # | Terms
#1 | “Peripheral Arterial Disease”[Mesh] OR “Peripheral Vascular Diseases”[Mesh] OR PAD[tiab] OR “peripheral arterial disease”[tiab] OR “peripheral vascular disease”[tiab] OR “arterial occlusive disease”[tiab] OR “intermittent claudication”[MeSH Terms] OR claudication[tiab] OR “rest pain”[tiab] OR (critical[tiab] AND (“extremities”[MeSH Terms] OR “extremities”[tiab] OR “limb”[tiab]) AND (“ischaemia”[tiab] OR “ischemia”[MeSH Terms] OR “ischemia”[tiab])) OR ((“ischaemia”[tiab] OR “ischemia”[MeSH Terms] OR “ischemia”[tiab]) AND (“lower extremity”[MeSH Terms] OR (“lower”[tiab] AND “extremity”[tiab]) OR “lower extremity”[tiab])) OR ((“extremities”[MeSH Terms] OR “extremities”[tiab] OR “limb”[tiab]) AND (“ischaemia”[tiab] OR “ischemia”[MeSH Terms] OR “ischemia”[tiab])) OR “vascular ulcer”[tiab] OR (vascular[tiab] AND ulcer[tiab]) OR “vascular ulcers”[tiab] OR (vascular[tiab] AND ulcers[tiab]) OR “varicose ulcer”[MeSH] OR “varicose ulcer”[tiab] OR (varicose[tiab] AND ulcer[tiab]) OR “varicose ulcers”[tiab] OR (varicose[tiab] AND ulcers[tiab]) OR “leg ulcer”[MeSH] OR “leg ulcer”[tiab] OR (leg[tiab] AND ulcer[tiab]) OR “leg ulcers”[tiab] OR (leg[tiab] AND ulcers[tiab]) OR gangrene[MeSH] OR gangrene[tiab]
#2 | “aspirin”[MeSH Terms] OR “aspirin”[tw] OR (“clopidogrel”[Supplementary Concept] OR “clopidogrel”[tw] OR “plavix”[tw]) OR “prasugrel”[Supplementary Concept] OR “prasugrel”[tw] OR Effient[tw] OR “Ticagrelor”[Supplementary Concept] OR “Ticagrelor”[tw] OR brilinta[tw]
#3 | “evaluation studies”[Publication Type] OR “evaluation studies as topic”[MeSH Terms] OR “evaluation study”[tw] OR evaluation studies[tw] OR “intervention studies”[MeSH Terms] OR “intervention study”[tw] OR “intervention studies”[tw] OR “case-control studies”[MeSH Terms] OR “case-control”[tw] OR “cohort studies”[MeSH Terms] OR cohort[tw] OR “longitudinal studies”[MeSH Terms] OR “longitudinal”[tw] OR longitudinally[tw] OR “prospective”[tw] OR prospectively[tw] OR “retrospective studies”[MeSH Terms] OR “retrospective”[tw] OR “follow up”[tw] OR “comparative study”[Publication Type] OR “comparative study”[tw] OR systematic[subset] OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[tw] OR “meta-analyses”[tw] OR randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR “drug therapy”[Subheading] OR randomly[tiab] OR trial[tiab] OR groups[tiab] OR Clinical trial[pt] OR “clinical trial”[tw] OR “clinical trials”[tw] NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp])NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp])
#4 | (#1 AND #2 AND #3 ) not (ANIMALS[MH] not HUMANS[MH])
#5 | #4 Limits: English, Publication Date from 1995 to 2011

Table A-2 KQ 2: Effectiveness and safety of exercise, medications, endovascular intervention, and surgical revascularization (intermittent claudication)

Set # | Terms
#1 | “intermittent claudication”[MeSH Terms] OR claudication[tiab]
#2 | (“angioplasty”[MeSH Terms] OR “angioplasty”[tiab] OR (“percutaneous”[tiab] AND “transluminal”[tiab] AND “angioplasty”[tiab]) OR “percutaneous transluminal angioplasty”[tiab]) OR PTA[tiab] OR (“stents”[MeSH Terms] OR “stents”[tiab] OR “stent”[tiab]) OR (percutaneous[tiab] AND revascularization[tiab]) OR (“endovascular procedures”[MeSH Terms] OR (“endovascular”[tiab] AND “procedures”[tiab]) OR “endovascular procedures”[tiab]) OR endovascular[tiab] OR (“exercise therapy”[MeSH Terms] OR (“exercise”[tiab] AND “therapy”[tiab]) OR “exercise therapy”[tiab]) OR ((“exercise”[MeSH Terms] OR “exercise”[tiab]) AND (program[tiab] OR class[tiab] OR training[tiab] OR prescribed[tiab] OR structure[tiab] OR structured[tiab] OR supervised[tiab])) OR (“aspirin”[MeSH Terms] OR “aspirin”[tiab]) OR (“clopidogrel”[Supplementary Concept] OR “clopidogrel”[tiab]) OR (“cilostazol”[Supplementary Concept] OR “cilostazol”[tiab]) OR (“pentoxifylline”[MeSH Terms] OR “pentoxifylline”[tiab])
#3 | “Femoral Artery/surgery”[Mesh] OR “Popliteal Artery/surgery”[Mesh] OR “tibial arteries/surgery”[Mesh Terms] OR “arteries/surgery”[Mesh Terms] OR “transplants”[MeSH Terms] OR transplants[tiab] OR graft[tiab] OR grafts[tiab] OR grafting[tiab] OR bypass[tiab] OR conduit[tiab] OR femoropopliteal[tiab] OR femorotibial[tiab] OR aortobifemoral[tiab] OR ballon[tiab] OR “atherectomy”[MeSH Terms] OR atherectomy[tiab]
#4 | “evaluation studies”[Publication Type] OR “evaluation studies as topic”[MeSH Terms] OR “evaluation study”[tw] OR evaluation studies[tw] OR “intervention studies”[MeSH Terms] OR “intervention study”[tw] OR “intervention studies”[tw] OR “case-control studies”[MeSH Terms] OR “case-control”[tw] OR “cohort studies”[MeSH Terms] OR cohort[tw] OR “longitudinal studies”[MeSH Terms] OR “longitudinal”[tw] OR longitudinally[tw] OR “prospective”[tw] OR prospectively[tw] OR “retrospective studies”[MeSH Terms] OR “retrospective”[tw] OR “follow up”[tw] OR “comparative study”[Publication Type] OR “comparative study”[tw] OR systematic[subset] OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[tw] OR “meta-analyses”[tw] OR randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR “drug therapy”[Subheading] OR randomly[tiab] OR trial[tiab] OR groups[tiab] OR Clinical trial[pt] OR “clinical trial”[tw] OR “clinical trials”[tw] NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp])NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp])
#5 | #1 AND (#2 OR #3) AND #4 NOT (animals[mh] NOT humans[mh])
#6 | #5 AND Limits: English, Publication Date from 1995 to 2011

Table A-3 KQ 3: Effectiveness and safety of endovascular intervention and surgical revascularization (critical limb ischemia)

Set # | Terms
#1 | “rest pain”[tiab] OR (critical[tiab] AND (“extremities”[MeSH Terms] OR “extremities”[tiab] OR “limb”[tiab]) AND (“ischaemia”[tiab] OR “ischemia”[MeSH Terms] OR “ischemia”[tiab])) OR ((“ischaemia”[tiab] OR “ischemia”[MeSH Terms] OR “ischemia”[tiab]) AND (“lower extremity”[MeSH Terms] OR (“lower”[tiab] AND “extremity”[tiab]) OR “lower extremity”[tiab])) OR ((“extremities”[MeSH Terms] OR “extremities”[tiab] OR “limb”[tiab]) AND (“ischaemia”[tiab] OR “ischemia”[MeSH Terms] OR “ischemia”[tiab]))
#2 | ”angioplasty”[MeSH Terms] OR “angioplasty”[tiab] OR (“percutaneous”[tiab] AND “transluminal”[tiab] AND “angioplasty”[tiab]) OR “percutaneous transluminal angioplasty”[tiab] OR PTA[tiab] OR “stents”[MeSH Terms] OR “stents”[tiab] OR “stent”[tiab] OR (percutaneous[tiab] AND revascularization[tiab]) OR “endovascular procedures”[MeSH Terms] OR endovascular[tiab]
#3 | “Femoral Artery/surgery”[Mesh] OR “Popliteal Artery/surgery”[Mesh] OR “tibial arteries/surgery”[Mesh Terms] OR “arteries/surgery”[Mesh Terms] OR “transplants”[MeSH Terms] OR transplants[tiab] OR graft[tiab] OR grafts[tiab] OR grafting[tiab] OR bypass[tiab] OR conduit[tiab] OR femoropopliteal[tiab] OR femorotibial[tiab] OR aortobifemoral[tiab] OR ballon[tiab] OR “atherectomy”[MeSH Terms] OR atherectomy[tiab]
#4 | “evaluation studies”[Publication Type] OR “evaluation studies as topic”[MeSH Terms] OR “evaluation study”[tw] OR evaluation studies[tw] OR “intervention studies”[MeSH Terms] OR “intervention study”[tw] OR “intervention studies”[tw] OR “case-control studies”[MeSH Terms] OR “case-control”[tw] OR “cohort studies”[MeSH Terms] OR cohort[tw] OR “longitudinal studies”[MeSH Terms] OR “longitudinal”[tw] OR longitudinally[tw] OR “prospective”[tw] OR prospectively[tw] OR “retrospective studies”[MeSH Terms] OR “retrospective”[tw] OR “follow up”[tw] OR “comparative study”[Publication Type] OR “comparative study”[tw] OR systematic[subset] OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[tw] OR “meta-analyses”[tw] OR randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR “drug therapy”[Subheading] OR randomly[tiab] OR trial[tiab] OR groups[tiab] OR Clinical trial[pt] OR “clinical trial”[tw] OR “clinical trials”[tw] NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp])NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp])
#5 | #1 AND (#2 OR #3) AND #4 NOT (animals[mh] NOT humans[mh])
#6 | #5 AND Limits: Publication Date from 1995 to 2011

## Embase^®^ Search Strategy (August 13, 2012)

Platform: Embase.com

Table A-4 KQ 1: Effectiveness and safety of aspirin and antiplatelets for patients with peripheral artery disease

Set # | Terms
#1 | ‘peripheral arterial disease’:ab,ti OR pad:ab,ti OR ‘peripheral artery disease’:ab,ti OR ‘peripheral occlusive artery disease’/de OR ‘claudication’/exp OR ‘limb ischemia’/exp OR ‘leg ischemia’/exp OR ‘leg ulcer’/exp OR ‘gangrene’/exp OR ‘intermittent claudication’:ab,ti OR ((extremity:ab,ti OR limb:ab,ti OR leg:ab,ti) AND (ischemia:ab,ti OR iscaemia:ab,ti))
#2 | aspirin:ab,ti OR clopidogrel:ab,ti OR plavix:ab,ti OR prasugrel:ab,ti OR effient:ab,ti OR ticagrelor:ab,ti OR brilinta:ab,ti OR ‘acetylsalicylic acid’/exp OR ‘clopidogrel’/exp OR ‘ticagrelor’/exp OR prasugrel/exp
#3 | ‘randomized controlled trial’/exp OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random*:ab,ti OR factorial*:ab,ti OR crossover*:ab,ti OR (cross NEAR/1 over*):ab,ti OR placebo*:ab,ti OR (doubl* NEAR/1 blind*):ab,ti OR (singl* NEAR/1 blind*):ab,ti OR assign*:ab,ti OR allocat*:ab,ti OR volunteer*:ab,ti OR ‘clinical study’/exp OR ‘clinical trial’:ab,ti OR ‘clinical trials’:ab,ti OR ‘controlled study’/exp OR ‘evaluation’/exp OR ‘evaluation study’:ab,ti OR ‘evaluation studies’:ab,ti OR ‘intervention study’:ab,ti OR ‘intervention studies’:ab,ti OR ‘case control’:ab,ti OR ‘cohort analysis’/exp OR cohort:ab,ti ORlongitudinal*:ab,ti OR prospective:ab,ti OR prospectively:ab,ti OR retrospective:ab,ti OR ‘follow up’/exp OR ‘follow up’:ab,ti OR ‘comparative effectiveness’/exp OR ‘comparative study’/exp OR ‘comparative study’:ab,ti OR ‘comparative studies’:ab,ti OR ‘evidence based medicine’/exp OR ‘systematic review’:ab,ti OR ‘meta-analysis’:ab,ti OR ‘meta-analyses’:ab,ti NOT (‘editorial’/exp OR ‘letter’/exp OR ‘case report’/exp)
#4 | #1 AND #2 AND #3
#5 | #4 AND [humans]/lim AND [1995-2012]/py
#6 | #5 AND [embase]/lim NOT [medline]/lim AND [1995-2012]/py

Table A-5 KQ 2: Effectiveness and safety of exercise, medications, endovascular intervention, and surgical revascularization (intermittent claudication)

Set # | Terms
#1 | ‘claudication’/exp OR claudication:ab,ti
#2 | ‘angioplasty’/exp OR ‘percutaneous transluminal angioplasty’/exp OR ‘stent’/exp OR ‘endovascular surgery’/de OR angioplasty:ab,ti OR “percutaneous transluminal”:ab,ti OR stent:ab,ti OR stents:ab,ti OR endovascular:ab,ti OR revascularization:ab,ti OR percutaneous:ab,ti OR pta:ab,ti OR ‘revascularization’/exp OR kinesiotherapy/exp OR (‘exercise’/exp AND (therapy:ab,ti OR program:ab,ti OR class:ab,ti OR training:ab,ti OR prescribed:ab,ti OR structure:ab,ti OR structured:ab,ti OR supervised:ab,ti)) OR ‘pentoxifylline’/exp OR ‘cilostazol’/exp OR pentoxifylline:ab,ti OR cilostazol:ab,ti OR aspirin:ab,ti OR clopidogrel:ab,ti OR ‘acetylsalicylic acid’/exp OR clopidogrel/exp
#3 | (‘leg artery’/exp OR femoropopliteal:ab,ti OR femorotibial:ab,ti OR aortobifemoral:ab,ti OR femoral;ab,ti OR popliteal:ab,ti OR tibial:ab,ti) AND (transplant:ab,ti OR graft:ab,ti OR grafts:ab,ti OR grafting:ab,ti OR bypass:ab,ti OR conduit:ab,ti OR ballon:ab,ti OR transplantation:ab,ti) OR ‘leg revascularization’/exp
#4 | ‘randomized controlled trial’/exp OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random*:ab,ti OR factorial*:ab,ti OR crossover*:ab,ti OR (cross NEAR/1 over*):ab,ti OR placebo*:ab,ti OR (doubl* NEAR/1 blind*):ab,ti OR (singl* NEAR/1 blind*):ab,ti OR assign*:ab,ti OR allocat*:ab,ti OR volunteer*:ab,ti OR ‘clinical study’/exp OR ‘clinical trial’:ab,ti OR ‘clinical trials’:ab,ti OR ‘controlled study’/exp OR ‘evaluation’/exp OR ‘evaluation study’:ab,ti OR ‘evaluation studies’:ab,ti OR ‘intervention study’:ab,ti OR ‘intervention studies’:ab,ti OR ‘case control’:ab,ti OR ‘cohort analysis’/exp OR cohort:ab,ti ORlongitudinal*:ab,ti OR prospective:ab,ti OR prospectively:ab,ti OR retrospective:ab,ti OR ‘follow up’/exp OR ‘follow up’:ab,ti OR ‘comparative effectiveness’/exp OR ‘comparative study’/exp OR ‘comparative study’:ab,ti OR ‘comparative studies’:ab,ti OR ‘evidence based medicine’/exp OR ‘systematic review’:ab,ti OR ‘meta-analysis’:ab,ti OR ‘meta-analyses’:ab,ti NOT (‘editorial’/exp OR ‘letter’/exp OR ‘case report’/exp)
#5 | #1 AND (#2 OR #3) AND #4
#6 | #5 AND [humans]/lim AND [1995-2012]/py
#7 | #6 AND [embase]/lim NOT [medline]/lim

Table A-6 KQ 3: Effectiveness and safety of endovascular intervention and surgical revascularization (critical limb ischemia)

Set # | Terms
#1 | “rest pain”:ab,ti OR ‘limb ischemia’/exp AND ‘leg ischemia’/exp OR “critical limb ischemia” )OR (critical:ab,ti AND ( extremities:ab,ti OR extremity:ab,ti OR limb:ab,ti OR leg:ab,ti) AND (“ischaemia”:ab,ti OR “ischemia”:ab,ti))
#2 | ‘angioplasty’/exp OR ‘percutaneous transluminal angioplasty’/exp OR ‘stent’/exp OR ‘endovascular surgery’/de OR angioplasty:ab,ti OR ‘percutaneous transluminal’:ab,ti OR stent:ab,ti OR stents:ab,ti OR endovascular:ab,ti OR revascularization:ab,ti OR percutaneous:ab,ti OR pta:ab,ti OR ‘revascularization’/exp
#3 | ‘leg artery’/exp OR femoropopliteal:ab,ti OR femorotibial:ab,ti OR aortobifemoral:ab,ti OR femoral;ab,ti OR popliteal:ab,ti OR tibial:ab,ti AND (transplant:ab,ti OR graft:ab,ti OR grafts:ab,ti OR grafting:ab,ti ORbypass:ab,ti OR conduit:ab,ti OR ballon:ab,ti OR transplantation:ab,ti) OR ‘leg revascularization’/exp
#4 | ‘randomized controlled trial’/exp OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random*:ab,ti OR factorial*:ab,ti OR crossover*:ab,ti OR (cross NEAR/1 over*):ab,ti OR placebo*:ab,ti OR (doubl* NEAR/1 blind*):ab,ti OR (singl* NEAR/1 blind*):ab,ti OR assign*:ab,ti OR allocat*:ab,ti OR volunteer*:ab,ti OR ‘clinical study’/exp OR ‘clinical trial’:ab,ti OR ‘clinical trials’:ab,ti OR ‘controlled study’/exp OR ‘evaluation’/exp OR ‘evaluation study’:ab,ti OR ‘evaluation studies’:ab,ti OR ‘intervention study’:ab,ti OR ‘intervention studies’:ab,ti OR ‘case control’:ab,ti OR ‘cohort analysis’/exp OR cohort:ab,ti ORlongitudinal*:ab,ti OR prospective:ab,ti OR prospectively:ab,ti OR retrospective:ab,ti OR ‘follow up’/exp OR ‘follow up’:ab,ti OR ‘comparative effectiveness’/exp OR ‘comparative study’/exp OR ‘comparative study’:ab,ti OR ‘comparative studies’:ab,ti OR ‘evidence based medicine’/exp OR ‘systematic review’:ab,ti OR ‘meta-analysis’:ab,ti OR ‘meta-analyses’:ab,ti NOT (‘editorial’/exp OR ‘letter’/exp OR ‘case report’/exp)
#5 | #1 AND (#2 OR #3) AND #4
#6 | #5 AND [humans]/lim AND [1995-2012]/py
#7 | #6 AND [embase]/lim NOT [medline]/lim

## Cochrane Search Strategy (August 13, 2012)

Platform: Wiley

Databases searched: Cochrane Central Registry of Controlled Trials and Cochrane Database of Systematic Reviews

Table A-7 KQ 1: Effectiveness and safety of aspirin and antiplatelets for patients with peripheral artery disease

Set # | Terms
#1 | MeSH descriptor Peripheral Arterial Disease explode all trees OR MeSH descriptor Intermittent Claudication explode all trees OR MeSH descriptor Leg Ulcer explode all trees OR MeSH descriptor Varicose Ulcer explode all trees OR MeSH descriptor Gangrene explode all trees OR (Peripheral Arterial Disease):ti,ab,kw or (arterial occlusive disease):ti,ab,kw or (intermittent claudication):ti,ab,kw or (rest pain):ti,ab,kw or (pad):ti,ab,kw OR (occlusive artery disease):ti,ab,kw or (leg ischemia):ti,ab,kw or (limb ischemia):ti,ab,kw or (claudication):ti,ab,kw
#2 | MeSH descriptor Aspirin explode all trees OR (aspirin):ti,ab,kw or (clopidogrel):ti,ab,kw or (prasugrel):ti,ab,kw or (ticagrelor):ti,ab,kw or (plavix):kw
#3 | #1 AND #2 AND (Cochrane Reviews, other reviews, Clinical trials)
#4 | #3 AND 1995 - 2012

Table A-8 KQ 2: Effectiveness and safety of exercise, medications, endovascular intervention, and surgical revascularization (intermittent claudication)

Set # | Terms
#1 | MeSH descriptor Intermittent Claudication explode all trees OR claudication):ti,ab,kw
#2 | MeSH descriptor Angioplasty explode all trees OR MeSH descriptor Stents explode all trees OR MeSH descriptor Endovascular Procedures explode all trees OR percutaneous transluminal):ti,ab,kw OR (pta):ti,ab,kw OR (endovascular):ti,ab,kw OR (revascularization):ti,ab,kw OR (stent OR stents):ti,ab,kw OR MeSH descriptor Exercise Therapy explode all trees OR (exercise):ti,ab,kw OR MeSH descriptor Aspirin explode all trees OR MeSH descriptor Pentoxifylline explode all trees OR (aspirin):ti,ab,kw or (clopidogrel):ti,ab,kw or (cilostazol):ti,ab,kw or (pentoxifylline):ti,ab,kw
#3 | MeSH descriptor Femoral Artery explode all trees with qualifier: SU OR MeSH descriptor Popliteal Artery explode all trees with qualifier: SU OR MeSH descriptor Tibial Arteries explode all trees with qualifier: SU OR MeSH descriptor Arteries explode all trees with qualifier: SU OR (graft*):ti,ab,kw or (transplant*):ti,ab,kw or (bypass):ti,ab,kw or (conduit):ti,ab,kw OR (femoropopliteal):ti,ab,kw or (femorotibial):ti,ab,kw or (aortobifermoral):ti,ab,kw or (atherectomy):ti,ab,kw OR (revascularization):ti,ab,kw
#4 | #1 AND (#2 OR #3)
#5 | #4 AND (Cochrane Reviews, other reviews, Clinical trials)
#6 | #5 AND 1995-2012

Table A-9 KQ 3: Effectiveness and safety of endovascular intervention and surgical revascularization (critical limb ischemia)

Set # | Terms
#1 | (rest pain):ti,ab,kw or (critical limb ischemia):ti,ab,kw OR (MeSH descriptor Ischemia explode all trees OR (ischemia):ti,ab,kw or (ischaemia):ti,ab,kw) AND ((limb*):ti,ab,kw or (leg*):ti,ab,kw or (extremiti*):ti,ab,kw)
#2 | MeSH descriptor Angioplasty explode all trees OR MeSH descriptor Stents explode all trees OR MeSH descriptor Endovascular Procedures explode all trees OR (percutaneous transluminal angioplasty):ti,ab,kw or (stent*):ti,ab,kw or (angioplasty):ti,ab,kw or (revascularization):ti,ab,kw or (endovascular):ti,ab,kw
#3 | MeSH descriptor Femoral Artery explode all trees with qualifier: SU OR MeSH descriptor Popliteal Artery explode all trees with qualifier: SU OR MeSH descriptor Tibial Arteries explode all trees with qualifier: SU OR MeSH descriptor Arteries explode all trees with qualifier: SU OR (transplant*):kw or (bypass):ti,ab,kw or (graft*):ti,ab,kw or (conduit*):ti,ab,kw or (ballon):ti,ab,kw OR (femoropopliteal):ti,ab,kw or (femorotibial):ti,ab,kw or (aortobifermoral):ti,ab,kw or (atherectomy):ti,ab,kw
#4 | #1 AND (#2 OR #3)
#5 | #4 AND (Cochrane Reviews, other reviews, Clinical trials)
#6 | #5 AND 1995-2012