# Abbreviations

ABI: ankle-brachial index
ACD: absolute claudication distance
AHRQ: Agency for Healthcare Research and Quality
ASA: acetylsalicylic acid (aspirin)
CI: confidence interval
CLI: critical limb ischemia
COT: claudication onset time
CV: cardiovascular
CVA: cerebrovascular accident
DAPT: Dual antiplatelet therapy
EffSE: standard error of effect
ES: effect size
HR: hazard ratio
IC: intermittent claudication
ICD: initial claudication distance
IDDM: insulin-dependent diabetes mellitus
KQ: key question
LDL: low-density lipoprotein
m: meters
MI: myocardial infarction
min: minute
mo: month/months
MWD: maximal walking distance
MWT: maximal walking time
NA: not applicable
NIDDM: noninsulin-dependent diabetes mellitus
NR: not reported
OR: odds ratio
PAD: peripheral artery disease
PAQ: Peripheral Artery Questionnaire
PFWD: pain-free walking distance
PICOTS: population, intervention, comparator, outcome, timing, setting
PTA: percutaneous transluminal angioplasty
PWD: peak walking distance
PWT: peak walking time
QOL: quality of life
RCT: randomized controlled trial
RR: risk ratio
SD: standard deviation
sec: second/seconds
SF-36^®^: short-form (36) health survey
SFA: superficial femoral artery
SOE: strength of evidence
TEP: Technical Expert Panel
TWD: total walking distance
WIQ: Walking Impairment Questionnaire
wk: week/weeks
yr: year/years