# Results

In what follows, we begin by presenting the results of our literature searches. The remainder of the chapter is organized by Key Question (KQ). Under each KQ, we begin by listing the key points of the findings, followed by a brief description of included studies and a study characteristics table, followed by a more detailed synthesis of the evidence. We conducted quantitative analyses (i.e., meta-analyses) where possible, as described in the Methods chapter. Results of these analyses are presented graphically in the form of forest plots and in tabular format. A list of abbreviations and acronyms used in this chapter is provided at the end of the report.

## Results of Literature Searches

Figure 3 depicts the flow of articles through the literature search and screening process. Searches of PubMed^®^, the Cochrane Database of Systematic Reviews, and Embase^®^ yielded 8256 citations, 1626 of which were duplicate citations. Manual searching identified 46 additional citations, for a total of 6676 citations. After applying inclusion/exclusion criteria at the title-and-abstract level, 1324 full-text articles were retrieved and screened. Of these, 1127 were excluded at the full-text screening stage, leaving 197 articles (representing 186 studies) for data abstraction. Appendix C provides a detailed listing of included articles as well as a key to study groupings of primary and companion articles. Appendix E provides a complete list of articles excluded at the full-text screening stage, with reasons for exclusion.

Figure 3 Literature flow diagram

KQ = Key Question

* Article counts by KQ do not add to 197 because some studies were included for multiple KQs.

Figure 3. Literature flow diagram. This figure depicts the flow of articles through the literature search and screening process. Searches of PubMed®, the Cochrane Database of Systematic Reviews, and Embase® yielded 8256 citations, 1626 of which were duplicate citations. Manual searching identified 46 additional citations, for a total of 6676 citations. After applying inclusion/exclusion criteria at the title-and-abstract level, 1324 full-text articles were retrieved and screened. Of these, 1127 were excluded at the full-text screening stage, leaving 197 articles (representing 186 studies) for data abstraction.

## Description of Included Studies

Overall, we included 186 studies represented by 197 articles: 60 studies were relevant to KQ 1, 99 studies to KQ 2, and 37 studies to KQ 3. Studies were conducted wholly or partly in continental Europe (37%), the United States or Canada (32%), the United Kingdom (7%), Asia (24%), South or Central America (4%), Australia or New Zealand (7%), and other locations (3%). In 11 studies, the location was not reported. Further details on the studies included for each KQ are provided in the relevant results sections below and in Appendix F.

As described in the Methods chapter, we searched ClinicalTrials.gov to identify completed but unpublished studies as a mechanism for ascertaining publication bias. Our search yielded 552 trial records, 257 of which were completed at least 1 year prior to our search of the database and review of the published literature. A single reviewer identified 35 of these records as potentially relevant. We identified and screened publications for 23 of the 35 trial records. Of the 12 trial records for which we did not identify publications, one was considered potentially relevant to KQ 2, and 11 were potentially relevant to KQ 3.

The one study potentially relevant to KQ 2 is an interventional study in patients diagnosed with PAH that was verified as completed with 75 patients in June 2011. It was designed to assess the correlation between plasma brain natriuretic peptide (BNP) and migration inhibitory factor (MIF) levels, both before and after exercise, with 6-minute walk distance (6MWD) and echocardiographic parameters as markers of PAH severity. This study remains unpublished, but if findings are available in the future, the data would add to the BNP correlations with 6MWD and echocardiographic parameters reported here. Although MIF was not in the list of commonly studied biomarkers that we focused on in this report, our findings support the need for additional research into alternative biomarkers that may more effectively assess disease severity.

Of the 11 studies potentially relevant to KQ 3, one was terminated when the drug sitaxsentan was withdrawn from the market, and another study focused on oral treprostinil, which was recently rejected by the FDA. Two more studies were terminated due to slow enrollment, and we could not find any published results. Of the seven remaining studies, four have data uploaded to ClinicalTrials.gov but have yet to be published in the peer-reviewed literature. These studies consist of a dose response study of oral sildenafil that was terminated, the EPITOME-1 and EPITOME-1 Extension studies comparing two types of injectable epoprostenol, and the ATHENA-1 study investigating the addition of ambrisentan to phosphodiesterase-5 (PDE5) inhibitor therapy. These four unpublished trials could potentially provide additional evidence on the comparative safety and effectiveness of pharmacological therapies for PAH in 197 patients. Note that the 37 studies included for KQ 3 involved data for 4192 patients.

The final three studies are either still recruiting, or their true status is unknown. One study, on the effect of treprostinil plus tadalafil versus tadalafil alone, was confirmed as still recruiting in February 2011 and would add to our knowledge of monotherapy versus combination therapy. The final two unpublished studies have not been updated in ClinicalTrials.gov in the last 2 years, and both are studies of novel drug treatments for PAH. One of these studies focuses on the safety and efficacy of fluoxetine, while the other focuses on an endothelin named BQ-123.

Based on our search of ClinicalTrials.gov and the 12 trial records without publications in peer-reviewed literature, we do not believe that there is significant publication bias in the evidence base that would impact our overall findings.

## KQ 1 Screening for PAH

KQ 1: For patients with suspected pulmonary arterial hypertension (PAH) and asymptomatic patients at high risk for PAH, what are the comparative effectiveness and safety of echocardiography versus echocardiography plus biomarkers as screening modalities before right heart catheterization to establish the diagnosis of PAH (diagnostic accuracy efficacy)?

### Key Points

- For patients suspected of having PAH with elevated systolic pulmonary artery pressure (sPAP) by echocardiography, additional testing with the biomarker N-terminal pro-B-type natriuretic peptide (NT-proBNP) may identify patients who do not have PAH compared with echocardiography sPAP alone (based on one good-quality prospective cohort study) (low strength of evidence).
- For patients suspected of PAH, echocardiographic estimation of right ventricular systolic pressure (RVSP) (or tricuspid gradient [TG]) by tricuspid regurgitation jet velocity (TRV), sPAP by TRV and right atrial pressure (RAP), and pulmonary vascular resistance (PVR) by TRV/velocity-time integral right ventricular outflow tract (VTI_RVOT_) show reasonably good accuracy compared with right heart catheterization (RHC) (moderate strength of evidence).
- For both asymptomatic patients at high risk for PAH or symptomatic patients suspected of PAH, natriuretic peptide testing (with either BNP or NT-proBNP) shows highly variable sensitivity and specificity estimates (not simultaneously high) for pulmonary hypertension (PH) or PAH diagnosis (low strength of evidence) and moderate correlation with hemodynamic measures by RHC (moderate strength of evidence).
- There were no studies of the safety of biomarker and echocardiography testing, nor were there any studies of combined echocardiographic and biomarker screening of asymptomatic patients at high risk for PAH (insufficient strength of evidence).

### Description of Included Studies

We identified 60 unique studies involving a total of 7,096 patients that described the effectiveness of echocardiography or biomarkers in patients with suspected PAH, or in asymptomatic patients at high risk for PAH, as screening modalities before right heart catheterization to establish the diagnosis of PAH.9,14,26–83 We identified one good-quality study26 involving 372 patients that compared echocardiography with echocardiography plus biomarkers in patients with suspected PAH, most of whom were symptomatic. There were no other studies directly comparing combinations of echocardiographic and biomarker testing. In order to draw inferences about the comparative effectiveness of other tests, we reviewed the diagnostic accuracy of independent echocardiographic or biomarker testing compared with RHC. By evaluating the relative diagnostic performance of these tests versus a reference standard of RHC, one can impute the comparative effectiveness via indirect comparisons.

Of the 60 included studies, 18 (30%) were rated good quality, 33 (55%) fair quality, and 9 (15%) poor quality. Echocardiographic parameters evaluated were right ventricular (RV) size, right atrium (RA) size, fractional area change (FAC), tricuspid annular plane systolic excursion (TAPSE), tricuspid lateral annular systolic velocity (S′), right ventricular index of myocardial performance (RIMP), myocardial performance index (MPI), Tei index, systolic pulmonary artery pressure (sPAP), mean pulmonary artery pressure (mPAP), tricuspid regurgitation jet velocity (TRV), velocity-time integral right ventricular outflow tract (VTI_RVOT_), right ventricular ejection fraction (RVEF), right ventricular systolic pressure (RVSP), and pericardial effusion. Biomarkers evaluated were natriuretic peptides, endothelin-1, uric acid, troponin T, nitric oxide, asymmetric dimethylarginine, cyclic guanosine monophosphate, and D-dimer.

#### Study Characteristics

Table F-1 in Appendix F summarizes the patient population, study size, test measures, study objectives, and quality rating for each study relevant to KQ 1. Of these studies, 26 were conducted in Europe (including the United Kingdom),14,26–30,32,35,36,39–41,46,54,55,57,58,60,66,68,70,71,73,76–78 17 in the United States,9,33,37,43,45,51–53,56,59,61,65,67,75,80,83 12 in Asia,38,47–49,62–64,69,72,79,82 5 in Australia/New Zealand,31,42,44,50,81 and 1 in South America.34 The vast majority of studies included only adults; exceptions were five studies that included only children45,63,64,74,82 and three studies that included both children and adults.65,69,79 In studies that reported the sex of participants, a total of 4020 participants were female and 1275 were male. Symptom status of study populations consisted of asymptomatic (3 studies; 481 patients), symptomatic (41 studies; 4394 patients), mixed (8 studies; 1186 patients), and symptoms not described (8 studies; 1035 patients). Of the included studies, 14 compared biomarker levels, 49 evaluated echocardiographic parameters, and 1 assessed echocardiography plus biomarkers as a testing or screening modality in patients with suspected PAH or asymptomatic patients at high risk for developing PAH. BNP and NT-proBNP were the most commonly evaluated biomarkers. The most commonly reported echocardiographic parameters compared with RHC were FAC, mPAP, RIMP, TRV/VTI_RVOT_, S′, sPAP, TRV, and TAPSE.

### Detailed Synthesis

#### Echocardiography Plus Biomarkers for Screening for PAH

We identified only one study (good quality) that gave data on the use of echocardiography and biomarkers in screening patients suspected of having PAH.26 This study used retrospective data on patients referred for evaluation of precapillary PH to develop a noninvasive diagnostic decision algorithm. This diagnostic algorithm was subsequently tested and validated in a prospective study using data from electrocardiography, serum NT-proBNP, and echocardiography. The goal was to use the aforementioned assessment to distinguish between patients in whom precapillary PH was likely versus those in whom precapillary PH could be excluded with the goal of avoiding unnecessary, invasive RHC procedures. Patients with neither RV strain on ECG (defined as ST-segment deviation and T-wave inversions in leads V1-V3) nor elevated serum NT-proBNP (>80 pg/mL) were considered to have the diagnosis of precapillary PH excluded despite elevated sPAP (≥36 mmHg) by echocardiography.

In 121 patients prospectively evaluated with this algorithm, 44 demonstrated RV strain, which alone had a sensitivity of 66 percent and specificity of 96 percent for identifying patients with precapillary PH. Among the remaining 69 patients, serum NT-proBNP level >80 pg/mL had 100 percent sensitivity and 24 percent specificity. Taken in combination with the decision algorithm, and in patients with echocardiographic estimates of sPAP ≥36 mmHg, the presence of either RV strain on ECG or serum NT-proBNP >80 pg/mL had a sensitivity of 100 percent and specificity of 19 percent for diagnosis of PAH based on RHC reference standard. By using this decision algorithm to exclude precapillary PH, the investigators concluded that 9 percent of referred patients with elevated sPAP by echocardiography (≥36 mmHg) could avoid undergoing invasive RHC. Excluding patients with RV strain on ECG, serum NT-proBNP testing would have avoided RHC in 16 percent of patients.

#### Biomarkers for Screening for PAH

Fourteen studies (4 good quality, 7 fair, and 3 poor) evaluated biomarkers in patients with and without PAH.14,26–28,35,43,58,63,64,68,71,73,79,81 Most studies were of natriuretic peptide (serum NT-proBNP or BNP); we found one study each for urinary cGMP,28 asymmetric dimethylarginine (ADMA)79 and plasma endothelin-1 (ET-1).64 Two studies evaluated biomarkers at baseline for an association with incident diagnosis of PAH,27,35 while the remaining studies evaluated concurrent biomarker and reference data.14,26,43,58,63,68,71,73,79,81 Five of these studies were case-control design.58,68,73,79,81 Four studies permitted calculation of sensitivity and specificity (of a NT-proBNP diagnostic threshold) for diagnosis of PAH (Table 5).26,58,68,81 One study permitted calculation of sensitivity and specificity of ADMA for diagnosis of PAH.79 The remaining studies were divided between those reporting biomarker group mean (or median) and standard deviation (or interquartile range) for groups with or without PAH (Table 6) and those reporting the correlation between biomarker level and hemodynamic measures from RHC in the form of a correlation coefficient (n=3)14,43,63 (Table 7).

Table 5 Diagnostic accuracy of biomarkers for PAH

Study Population (N) Quality | Biomarker | Test Threshold | Reference Diagnostic Criterion | TP | FN | FP | TN | Sensitivity (95% CI) | Specificity (95% CI) | Prevalence
Allanore, 2008^27^ SSc patients with echocardiography sPAP<40 mmHg and no NYHA III/IV symptoms (N=101) Good | NT-proBNP | >97^th^ percentile for age/sex | mPAP ≥25 mmHg | 6 | 3 | 16 | 77 | 67 (35 to 88) | 83 (74 to 89) | 8.8%
Bonderman, 2011^26^ Referred for evaluation of suspected PAH; more than half had NYHA III/IV symptoms (N=372) Good | NT-proBNP | >80pg/mL | mPAP >25 mmHg, PCWP <15 mmHg | 23 | 0 | 35 | 11 | 100 (88 to 100) | 24 (13 to 39) | 33%
Frea, 2011^35^ SSc patients with no signs or symptoms of PAH (N=76) Fair | NT-proBNP | >97^th^ percentile for age/sex | mPAP ≥25 mmHg | 1 | 3 | 6 | 28 | 25 (4.6 to 70) | 82 (67 to 92) | 10.5%
Simeoni, 2008^58^ Known SSc-associated PAH and controls with SSc but no PAH (N=20) Poor | NT-proBNP | ≥125 pg/mL | mPAP | 9 | 1 | 3 | 7 | 90 (55 to 100) | 70 (35 to 93) | 50%
Thakkar, 2012^81^ SSc patients with PAH, at high risk for PAH, with ILD, or SSc controls without PAH (N=94) Fair | NT-proBNP | ≥209.8 pg/mL | mPAP ≥25 mmHg, PCWP ≤15 mmHg | 14 | 1 | 0 | 30 | 93 (81 to 100) | 100 (90 to 100) | 33% (PAH vs. SSc controls)
Thakkar, 2012^81^ SSc patients with PAH, at high risk for PAH, with ILD, or SSc controls without PAH (N=94) Fair | NT-proBNP | ≥209.8 pg/mL | mPAP ≥25 mmHg, PCWP ≤15 mmHg | 13 | 2 | 0 | 19 | 87 (70 to 100) | 100 (84 to 100) | 44% (PAH vs. ILD)
Williams, 2006^68^ SSc patients with PAH and controls with SSc but without PAH (N=109) Fair | NT-proBNP | >91 pg/mL | mPAP >25mmHg at rest or >30mmHg with exercise, PCWP <15 mmHg | 38 | 30 | 2 | 39 | 56 (43 to 68) | 95 (83 to 99) | 62%
Sanli, 2012^79^ Children with unrepaired CHD with or without PAH and healthy controls (N=70) Fair | ADMA | >17 μmol/L | mPAP ≥25 mmHg, PCWP ≤15 mmHg | 21 | 9 | 10 | 10 | 70 (54 to 86) | 50 (28 to 72) | 60%

ADMA = asymmetric dimethylarginine; CHD = congenital heart disease; FN = false negative; FP = false positive; ILD = interstitial lung disease; mmHg = millimeter of mercury; mPAP = mean pulmonary artery pressure; NT-proBNP = N-terminal pro-B-type natriuretic peptide; NYHA = New York Heart Association; PAH = pulmonary arterial hypertension; PCWP = pulmonary capillary wedge pressure; SSc = systemic sclerosis; sPAP = systolic pulmonary artery pressure; TN = true negative; TP = true positive

Table 6 Biomarker levels by diagnostic group

Study Population (N) Quality | Biomarker | Reference Diagnostic Criterion for PAH | Patients With PAH | | Patients Without PAH | | Summary Measure
Study Population (N) Quality | Biomarker | Reference Diagnostic Criterion for PAH
Study Population (N) Quality | Biomarker | Reference Diagnostic Criterion for PAH | N | Mean (SD) (pg/mL) | N | Mean (SD) (pg/mL) | Criteria for Verification by RHC
Allanore, 2008^27,a^ SSc patients with echocardiography sPAP <40 mmHg and no NYHA III/IV symptoms (N=101) Good | NT-proBNP | mPAP ≥25 mmHg, PCWP ≤15 mmHg | 8 | 413 (304) | 93 | 127 (135) | sPAP >40 mmHg, DLCO <50% predicted without pulmonary fibrosis or unexplained dyspnea, negative CT, D-dimer
Bonderman, 2011^26^ Referred for evaluation of suspected PAH; more than half had NYHA III/IV symptoms (N=372) Good | NT-proBNP | mPAP >25 mmHg, PCWP <15 mmHg | 64 | 3648 (6541) | 57 | 1489 (3518) | sPAP ≥36 mmHg
Cavagna, 2010^14^ SSc patients; symptoms not described (N=135) Good | NT-proBNP | mPAP >25 mmHg, PCWP <15 mmHg | 20 | 189 (44 to 665)^a^ | 115 | 84 (39 to 181)^b^ | sPAP ≥36 mmHg
Frea, 2011^35,a^ SSc patients with no signs or symptoms of PAH (N=76) Fair | NT-proBNP | mPAP ≥25 mmHg, PCWP ≤15 mmHg | 4 | 211 (134) | 34 | 127 (100) | TRV ≥3 m/s or sPAP ≥40 mmHg
Ghio, 2004^73^ HIV and confirmed PAH; controls with HIV and no known cardiac or pulmonary disease (N=93) Fair | NT-proBNP | NR | 16 | 1412 (574 to 2326)^a^ | 77 | 29 (7 to 48)^b^ | NR (case-control design)
Simeoni, 2008^58^ Known SSc-associated PAH and controls with SSc but no PAH (N=20) Poor | NT-proBNP | NR | 10 | 198 | 10 | 103 | NR (case-control design)
Thakkar, 2012^81^ SSc patients with PAH, at high risk for PAH, with ILD, or SSc controls without PAH (N=94) Fair | NT-proBNP | mPAP ≥25 mmHg, PCWP ≤15 mmHg | 15 | 1818 (2367) | 19 (ILD) | 133 (87) | Echo sPAP ≥40 mmHg or DLCO ≤50% predicted with FVC >85%, DLCO ≥20% or unexplained dyspnea
Thakkar, 2012^81^ SSc patients with PAH, at high risk for PAH, with ILD, or SSc controls without PAH (N=94) Fair | NT-proBNP | mPAP ≥25 mmHg, PCWP ≤15 mmHg | 15 | 1818 (2367) | 30 (SSc) | 72 (38) | Echo sPAP ≥40 mmHg or DLCO ≤50% predicted with FVC >85%, DLCO ≥20% or unexplained dyspnea
Thakkar, 2012^81^ SSc patients with PAH, at high risk for PAH, with ILD, or SSc controls without PAH (N=94) Fair | NT-proBNP | mPAP ≥25 mmHg, PCWP ≤15 mmHg | 15 | 1818 (2367) | 30 (risk) | 278 (243) | Echo sPAP ≥40 mmHg or DLCO ≤50% predicted with FVC >85%, DLCO ≥20% or unexplained dyspnea
Williams, 2006^68^ SSc patients with PAH and controls with SSc but without PAH (N=109) Fair | NT-proBNP | NR, but PCWP ≤15 mmHg required | 68 | 1474 (2642) | 41 | 139 (150) | NA (case-control design; all patients had RHC)
Cavagna, 2010^14^ SSc patients; symptoms not described (N=135) Good | BNP | mPAP ≥25 mmHg, PCWP <15 mmHg | 20 | 74.5 (29 to 196)^a^ | 115 | 30 (18 to 49)^b^ | sPAP ≥36 mmHg, DLCO <50%pred, 20% decrease DLCO in 1 yr in absence of pulmonary fibrosis, or unexplained dyspnea, negative CT
Gialafos, 2008^71^ SSc patients; some symptomatic (N=106) Fair | BNP | NR | 37 | 163 (159) | 69 | 33 (23) | sPAP >40 mmHg (18/37 patients verified by RHC)
Sanli, 2012^79^ Children with unrepaired CHD with or without PAH and healthy controls (N=70) Fair | ADMA | mPAP≥25 mmHg, PCWP ≤ 15 mmHg | 30 | 23.1 (9.2) | 20 | 19.6 (7.4) (CHD controls) | All patients verified by RHC
Sanli, 2012^79^ Children with unrepaired CHD with or without PAH and healthy controls (N=70) Fair | ADMA | mPAP≥25 mmHg, PCWP ≤ 15 mmHg | 30 | 23.1 (9.2) | 20 | 17.1 (5.6) (healthy controls) | All patients verified by RHC
Bogdan, 1998^28^ PAH patients (N=19) and controls (N=30) Poor | Urinary cGMP | NR | 19 | 251 (26) nmol/mmol creatinine | 30 | 51 (4) healthy controls | NR (case-control design)
Bogdan, 1998^28^ PAH patients (N=19) and controls (N=30) Poor | Urinary cGMP | NR | 19 | 251 (26) nmol/mmol creatinine | 7 | 71 (8) asthmatic controls | NR (case-control design)
Tutar 1999^64^ Children with left-to-right shunt (N=23) and healthy controls (N=11) Fair | Plasma endothelin-1 (ratio of pulmonary venous and systemic venous level) | Ratio of simultaneous mPAP to aortic mean pressure > 0.5 | 9 | 1.10 (0.35) | 14 | 0.90 (0.16) | NR (case-control design)

ADMA = asymmetric dimethylarginine; CHD = congenital heart disease; CT = computed tomography; DLCO = diffusion capacity of the lung for carbon monoxide; FVC = forced vital capacity; ILD = interstitial lung disease; mmHg = millimeter of mercury; mPAP = mean pulmonary artery pressure; m/s = meters per second; NT-proBNP = N-terminal pro-B-type natriuretic peptide; NYHA = New York Heart Association; PAH = pulmonary arterial hypertension; PCWP = pulmonary capillary wedge pressure; RHC = right heart catheterization; SD = standard deviation; sPAP = systolic pulmonary artery pressure; RHC = right heart catheterization; yr = year/years

a Studies that assessed baseline NT-proBNP as predictors of future development of PAH.

b Median interquartile range.

Table 7 Correlations of biomarkers with RHC in PAH

Study Population (N) Quality | Biomarker | RHC Parameter | Total N | Correlation (p-value)
Machado, 2006^43^ Sickle cell disease (N=416) Poor | NT-proBNP | CO | 37 | −0.43 (0.006)
Machado, 2006^43^ Sickle cell disease (N=416) Poor | NT-proBNP | mPAP | 37 | 0.43 (0.006)
Machado, 2006^43^ Sickle cell disease (N=416) Poor | NT-proBNP | PVR (NR) | 37 | 0.51 (0.001)
Machado, 2006^43^ Sickle cell disease (N=416) Poor | NT-proBNP | sPAP | 37 | 0.59 (0.002)
Thakkar, 2012^81^ SSc patients with PAH, at high risk for PAH, with ILD or SSc controls without PAH (N=94) Fair | NT-proBNP | mPAP | 15 | 0.63 (0.013)
Thakkar, 2012^81^ SSc patients with PAH, at high risk for PAH, with ILD or SSc controls without PAH (N=94) Fair | NT-proBNP | mRAP | 15 | 0.77 (0.006)
Thakkar, 2012^81^ SSc patients with PAH, at high risk for PAH, with ILD or SSc controls without PAH (N=94) Fair | NT-proBNP | PVR | 15 | 0.76 (0.005)
Thakkar, 2012^81^ SSc patients with PAH, at high risk for PAH, with ILD or SSc controls without PAH (N=94) Fair | NT-proBNP | sPAP | 94 | 0.65 (<0.0001)
Cavagna, 2010^14^ SSc patients; symptoms not described (N=135) Good | NT-proBNP | mPAP | 115 | 0.61 (0.001)
Cavagna, 2010^14^ SSc patients; symptoms not described (N=135) Good | BNP | mPAP | 135 | 0.72 (0.002)
Toyono, 2008^63^ Children with VSD and severe PH (N=24) Good | BNP | PVR (Fick) | 24 | 0.56 (0.004)
Sanli, 2012^79^ Children with unrepaired CHD with or without PAH and healthy controls (N=70) Fair | ADMA | mPAP | 30 | −0.10 (>0.05)
Sanli, 2012^79^ Children with unrepaired CHD with or without PAH and healthy controls (N=70) Fair | ADMA | sPAP | 30 | −0.02 (>0.05)
Sanli, 2012^79^ Children with unrepaired CHD with or without PAH and healthy controls (N=70) Fair | ADMA | PVR | 30 | −0.19 (>0.05)
Sanli, 2012^79^ Children with unrepaired CHD with or without PAH and healthy controls (N=70) Fair
Bogdan, 1998^28^ PAH patients (N=19) and controls (N=30) Poor | Urinary cGMP | Cardiac Index | 19 | −0.65 (0.003)
Tutar 1999^64^ Children with left-to-right shunt (N=23) and healthy controls (N=11) Fair | Plasma endothelin-1 level (ratio of pulmonary to systemic venous) | mPAP | 23 | 0.57 (<0.005)

ADMA = asymmetric dimethylarginine; BNP = B-type natriuretic peptide; CO = cardiac output; mPAP = mean pulmonary artery pressure; mRAP = mean right atrial pressure; NR = not reported; NT-proBNP = N-terminal pro-B-type natriuretic peptide; PAH = pulmonary arterial hypertension; sPAP = systolic pulmonary artery pressure; PVR = pulmonary vascular resistance; RHC = right heart catheterization

##### Predicting Incidence of PAH

Two studies of patients with systemic sclerosis reported NT-proBNP levels measured at baseline among patients subsequently diagnosed with PAH.27,35 At baseline, patients were either without any signs or symptoms suggesting PAH35 or with no NYHA class III or IV symptoms and echocardiographic estimate of sPAP less than 40 mmHg.27 In both studies, patients were followed over time for development of symptoms or echocardiographic evidence of elevated sPAP. In followup ranging between 12 mo35 and 36 mo,27 approximately 10 percent of patients developed PAH in each study (Table 6).

Mean NT-proBNP levels at baseline were significantly higher among patients subsequently diagnosed with PAH in one study,27 but not significantly so in the other.35 This may be related to smaller numbers of patients with PAH or use of a lower mPAP threshold for diagnosis of PAH (25mmHg rather than 35mmHg). Applying a diagnostic threshold based on the 97^th^ percentile by sex and age group in healthy subjects, these two studies found nearly identical specificity, around 83 percent, but sensitivity estimates that are lower with wide confidence limits (Figure 4).

Figure 4 Sensitivity and specificity of NT-proBNP levels for predicting development of PAH

CI = confidence interval; FN = false negative; FP = false positive; TN = true negative; TP = true positive

Figure 4. Sensitivity and specificity of NT-proBNP levels for predicting development of PAH. This figure presents the sensitivity and specificity for two studies of patients with systemic sclerosis that reported NT-proBNP levels measured at baseline among patients subsequently diagnosed with PAH. These two studies found nearly identical specificity, around 83 percent, but sensitivity estimates that are lower with wide confidence limits.

##### Diagnosis of Prevalent PAH

Four studies evaluated NT-proBNP for diagnosing PAH; three studies used a case-control design among patients with systemic sclerosis, comparing cases with known PAH to controls with systemic sclerosis but no PAH (Figure 5).58,68,81 The fourth study included patients referred for evaluation of suspected PAH, but without a specific high-risk diagnosis.26 Thresholds for NT-proBNP ranged from 80 to 360 pg/mL; except for one study,81 thresholds were set relatively low compared with the normal ranges. Estimates of the sensitivity and specificity are quite different among these three studies. Differences between sensitivity and specificity estimates among these studies likely stem from both the inclusion criteria and the designs of the study by Bonderman et al.,26 in which patients were included only if they had elevated sPAP (>36 mmHg) by echocardiography, leading to a population with a high proportion of patients who had elevated NT-proBNP levels. Furthermore, all patients were first screened for evidence of RVH on ECG, before results of NT-proBNP testing were assessed.

Figure 5 Sensitivity and specificity of NT-proBNP for diagnosis of PAH

CI = confidence interval; FN = false negative; FP = false positive; TN = true negative; TP = true positive

Figure 5. Sensitivity and specificity of NT-proBNP for diagnosis of PAH. This figure presents sensitivity and specificity for four studies that evaluated NT-proBNP for diagnosing PAH; three studies used a case-control design among patients with systemic sclerosis, comparing cases with known PAH to controls with systemic sclerosis but no PAH. Estimates of the sensitivity and specificity are quite different among these three studies. Differences between sensitivity and specificity estimates among these studies likely stem from both the inclusion criteria and the designs of the study by Bonderman et al. in which patients were included only if they had elevated sPAP (>36 mmHg) by echocardiography, leading to a population with a high proportion of patients who had elevated NT-proBNP levels.

Eight studies reported biomarker levels by PAH diagnosis.14,26,58,68,71,73,79,81 Five studies included patients with systemic sclerosis,14,58,68,71,81 one included children with congenital heart disease,79 one included HIV-positive patients,73 and one (previously described) included patients referred for suspicion of PAH without a specific high-risk diagnosis.26 Although serum BNP and NT-proBNP levels were consistently more elevated in patients with PAH than those without PAH in these studies, this was represented by a wide range of mean values between studies (Table 6). Three studies reported on a single biomarker each.28,64,79 ADMA levels were higher among children with PAH and unrepaired congenital heart disease (CHD) than among healthy controls (p<0.0001) but not statistically different between those with PAH and unrepaired CHD versus controls with unrepaired CHD but no PAH (p>0.05).79 Urinary cGMP levels were significantly higher among patient with PPH than controls with acute asthma (p<0.001) or healthy controls (p<0.001).28 Among children with congenital heart disease with left-to-right shunt, the ratio of pulmonary venous to systemic venous plasma endothelin-1 level distinguished those with PH from those without (p<0.01).64

Four studies examined the correlation between either serum BNP or NT-proBNP levels and hemodynamic parameters measured at RHC. Statistically significant correlations were found between the biomarker level and CO, mPAP, PVR, mean right atrial pressure (mRAP), and sPAP; these correlations were of moderate strength for all parameters (Table 7). One study of ADMA found no correlation between ADMA levels and mPAP, sPAP, or PVR.79 One study each of urinary cGMP28 and plasma endothelin-1^64^ reported isolated positive correlations among many negative correlations for which incomplete data were reported.

#### Echocardiography for Diagnosing PAH

Twenty-six studies assessed echocardiography in evaluating patients suspected of PAH. All studies reported data that compared a single hemodynamic parameter at a time. Nineteen studies (6 good quality, 10 fair, 3 poor) reported the diagnostic accuracy of echocardiographic estimates of pulmonary pressures based on TRV measurement, with or without estimate of RAP, compared with a reference standard diagnosis based on RHC (Table 8).29,30,32,34,36–40,42,46,50,51,59,60,75,77,78,83

Table 8 Diagnostic accuracy of echocardiographic parameters for diagnosis of PAH

Study Population (N) Quality | Test Parameter | Test Threshold | Reference Diagnostic Criterion | TP | FN | FP | TN | Sensitivity (95% CI) | Specificity (95% CI) | Prevalence
Hua, 2008^38^ Liver transplant candidates (N=105) Good | sPAP 4 * TRV^2^ + RAP | ≥30 mmHg | mPAP ≥25 mmHg (PVR ≥240 dyne*sec/cm^5^ PCWP <15 mmHg | 4 | 0 | 18 | 83 | 100 (47 to 100) | 82 (73 to 89) | 4%
Torregrosa, 2001^60^ Liver transplant candidates (N=94) Fair | sPAP 4 * TRV^2^ + 10 | ≥40 mmHg | mPAP ≥25 mmHg or PVR >120 dynes*s/cm^5^ | 4 | 1 | 3 | 35 | 80 (45 to 100) | 92 (84 to 96) | 12%
Torregrosa, 2001^60^ Liver transplant candidates (N=94) Fair | sPAP, PAT | sPAP ≥40 mmHg or PAT <100 ms | mPAP ≥25 mmHg or PVR >120 dynes*s/cm^5^ | 5 | 0 | 5 | 33 | 100 (40 to 100) | 87 (76 to 98) | 12%
Phung, 2009^50^ SSc patients referred with or without suspicion of PAH; 10% had NYHA III/IV symptoms (N=184) Good | sPAP 4 * TRV^2^ + 10 | >40 mmHg | mPAP ≥25 mmHg | 23 | 0 | 18 | 119 | 100 (88 to 100) | 87 (80 to 92) | 14%
Pilatis, 2000^51^ Liver transplant candidates (N=55) Fair | sPAP 4 * TRV^2^ + RAP | >40 mmHg | mPAP ≥25 mmHg | 5 | 3 | 1 | 46 | 62 (24 to 91) | 98 (89 to 100) | 14%
Ruiz-Irastorza, 2012^78^ SLE patients in cohort study, regardless of symptoms of dyspnea (N=245) Fair | sPAP 4 * TRV^2^ + 5 | ≥40 mmHg | mPAP ≥25 mmHg | 12 | 0 | 19 | 212 | 100 (75 to 100) | 92 (88 to 95) | 5%
Ruiz-Irastorza, 2012^78^ SLE patients in cohort study, regardless of symptoms of dyspnea (N=245) Fair | sPAP 4 * TRV^2^ + 5 | ≥30 mmHg | mPAP ≥25 mmHg | 12 | 0 | 110 | 121 | 100 (75 to 100) | 52 (46 to 59) | 5%
Ruiz-Irastorza, 2012^78^ SLE patients in cohort study, regardless of symptoms of dyspnea (N=245) Fair | sPAP 4 * TRV^2^ + 5 | ≥40 mmHg *2 | mPAP ≥25 mmHg | 12 | 0 | 5 | 226 | 100 (75 to 100) | 98 (96 to 100) | 5%
Steen, 2008^59^ SSc patients with suspected PAH based on symptoms or signs (N=54) Fair | sPAP 4 * TRV^2^ + 10 | >20 mmHg increase over resting | mPAP >25 mmHg (rest) or >30 mmHg (exercise) | 21 | 5 | 3 | 25 | 81 (61 to 93) | 89 (72 to 98) | 48%
Colle, 2003^29^ Liver transplant candidates (N=165) Good | sPAP 4 * TRV^2^ + RAP | ≥30 mmHg | mPAP >25 PCWP <15 PVR >120 dynes*s/cm^5^ | 8 | 2 | 6 | 149 | 80 (44 to 97) | 96 (92 to 99) | 6%
Hsu, 2008^37^ SSc patients with dyspnea or other clinical features suggestive of PAH (N=49) Good | sPAP 4 * TRV^2^ + 10 | >47 mmHg | sPAP>25 mmHg | 14 | 10 | 1 | 24 | 58 (37 to 78) | 96 (80 to 100) | 49%
Denton, 1997^32^ SSc patients suspected of PAH, most due to reduced DLCO (N=93) Fair | sPAP 4 * TRV^2^ + JVP | ≥30 mmHg | sPAP ≥30 mmHg “provided PCWP was normal” | 19 | 2 | 3 | 9 | 90 (70 to 99) | 75 (43 to 95) | 64%
Kovacs, 2010^40^ Patients with CVD some with symptoms (N=52) Good | sPAP 4 * TRV^2^ + RAP | >40 mmHg | sPAP >40 mmHg with exercise and PCWP ≤20 mmHg | 11 | 5 | 10 | 18 | 69 (41 to 89) | 64 (44 to 81) | 36%
Arcasoy, 2003^83^ Advanced lung disease, undergoing evaluation for lung transplantation (N=374) Good | sPAP | ≥45 mmHg | sPAP ≥45 by RHC | 51 | 9 | 48 | 58 | 85 (73 to 93) | 55 (45 to 64) | 36%
Arcasoy, 2003^83^ Advanced lung disease, undergoing evaluation for lung transplantation (N=374) Good | RV finding | RVH, dilation or systolic dysfunction | sPAP ≥45 by RHC | 78 | 17 | 120 | 157 | 82 (73 to 89) | 57 (51 to 62) | 27%
Mukerjee, 2004^46^ SSc patients with suspected PAH, symptoms of exercise limitation and reduced DLCO (N=137) Fair | TG 4 * TRV^2^ | ≥40 mmHg | mPAP>25mmHg or resting PVR>200 dyne*sec/cm^5^ mPAP>30mmHg with exercise | 57 | 42 | 5 | 33 | 58 (47 to 67) | 87 (72 to 96) | 72%
Condliffe, 2011^30^ SSc patients with suspected PAH; symptoms not described (N=89) Fair | TRV | ≥35 mmHg (≥2.96 m/s) | mPAP ≥ 25 mmHg and PCWP ≤15 mmHg | 42 | 5 | 10 | 10 | 89 (77 to 96) | 50 (27 to 73) | 70%
Fitzgerald, 2012^75^ Adults with SCD (N=75) Poor | TRV | ≥ 2.5 m/s | mPAP ≥ 25 mmHg | 9 | 0 | 16 | 50 | 100 (67 to 100) | 76 (65 to 86) | 12%
Fitzgerald, 2012^75^ Adults with SCD (N=75) Poor | TRV | ≥ 2.5 m/s | mPAP≥25 mmHg and PCWP ≤15 mmHg | 3 | 0 | 22 | 50 | 100 (0 to 100) | 69 (59 to 80) | 4%
Fonseca, 2012^34^ Sickle cell disease; symptoms not described (N=80) Fair | TRV | >2.5 m/s | mPAP ≥25 mmHg | 8 | 0 | 18 | 48 | 100 (62 to 100) | 73 (62 to 84) | 11%
Fonseca, 2012^34^ Sickle cell disease; symptoms not described (N=80) Fair | TRV | >2.5 m/s | mPAP ≥25 mmHg and PCWP ≤15 mmHg | 3 | 0 | 23 | 48 | 100 (0 to 100) | 68 (57 to 78) | 4%
Hachulla, 2005^36^ SSc patients; some symptomatic (N=599) Poor | TRV | ≥3 m/s or ≥2.5 m/s with unexplained dyspnea | mPAP ≥25 mmHg rest or ≥30 mmHg with exercise and PCWP ≤15 mmHg | 18 | 0 | 15 | 419 | 100 (85 to 100) | 97 (94 to 98) | 4%
Jansa, 2011^39^ SSc patients some with dyspnea (N=203) Fair | TRV | >30 mmHg (>2.74 m/s) | mPAP ≥25 mmHg and PCWP ≤15 mmHg | 6 | 0 | 10 | 186 | 100 (61 to 100) | 95 (91 to 98) | 3%
Low, 2011^42^ Referred for evaluation of suspected or definite PAH, most with symptoms (N=200) Poor | TRV | ≥36 mmHg (≥3 m/s) | mPAP >25 mmHg PCWP, LAP or LVEDP ≤15 mmHg PVR >3WU | 58 | 0 | 8 | 128 | 100 (95 to 100) | 94 (89 to 97) | 30%
Rajaram, 2012^77^ CTD suspected of PH based on symptoms or screening tests (N=81) Fair | TRV | NR | mPAP ≥25 mmHg and PCWP ≤15 mmHg | 27 | 28 | 4 | 18 | 49 (36 to 62) | 82 (66 to 98) | 71%
Rajaram, 2012^77^ CTD suspected of PH based on symptoms or screening tests (N=81) Fair | TRV | ≥ 30 mmHg (≥2.74 m/s) | mPAP ≥25 mmHg and PCWP ≤15 mmHg | 52 | 3 | 13 | 9 | 95 (89 to 100) | 41 (20 to 62) | 71%
Rajaram, 2012^77^ CTD suspected of PH based on symptoms or screening tests (N=81) Fair | TRV | ≥40 mmHg (≥3.16 m/s) | mPAP ≥25 mmHg and PCWP ≤15 mmHg | 47 | 8 | 4 | 18 | 86 (76 to 95) | 82 (66 to 98) | 71%
Rajaram, 2012^77^ CTD suspected of PH based on symptoms or screening tests (N=81) Fair | TRV | ≥50 mmHg (≥3.54 m/s) | mPAP ≥25 mmHg and PCWP ≤15 mmHg | 39 | 16 | 1 | 21 | 71 (59 to 83) | 95 (87 to 100) | 71%
Dahiya, 2010^31^ Referred for evaluation of suspected PH; all patients had dyspnea (N=114) Good | TRV/VTI_RVOT_ | >0.16 | PVR >2 WU | 47 | 3 | 2 | 20 | 94 (83 to 99) | 91 (71 to 99) | 69%
Lindqvist, 2011^41^ Patients with PH undergoing RHC (N=30) Fair | TRV/VTI_RVOT_ | >0.175 | PVR >3 WU | 16 | 2 | 1 | 6 | 88 (65 to 99) | 86 (42 to 100) | 72%
Rajagopalan, 2009^52^ Known pulmonary hypertension (N=52) Fair | TRV/VTI_RVOT_ | >0.16 | PVR >2 WU | 41 | 4 | 0 | 7 | 91 (79 to 98) | 100 (65 to 100) | 87%
Roule, 2010^55^ Known PH (N=37) Good | TRV/VTI_RVOT_ | >0.14 | PVR >2 WU | 28 | 2 | 3 | 4 | 93 (78 to 99) | 57 (18 to 90) | 81%
Vlahos, 2007^65^ Known or suspected pulmonary hypertension (N=12) Fair | TRV/VTI_RVOT_ | >0.38 | PVR >8 WU | 6 | 2 | 0 | 4 | 75 (35 to 97) | 100 (47 to 100) | 67%
Ajami, 2011^68,69^ Children and young adults with congenital heart disease referred for RHC (N=20) Good | TRV/VTI_RVOT_ | >0.2 | PVR >8 WU | 9 | 1 | 1 | 9 | 90 (55 to 100) | 90 (55 to 100) | 50%
Cevik, 2012^74^ Children with CHD and healthy controls (N=70) Fair | RVMPI | NR | mPAP ≥25 mmHg and PCWP ≤15 mmHg | 14 | 16 | 2 | 38 | 47 (29 to 64) | 95 (88 to 100) | 43%
Cevik, 2012^74^ Children with CHD and healthy controls (N=70) Fair | S’ | NR | mPAP ≥25 mmHg and PCWP ≤15 mmHg | 21 | 9 | 2 | 38 | 70 (54 to 86) | 95 (88 to 100) | 43%
Cevik, 2012^74^ Children with CHD and healthy controls (N=70) Fair | sPAP/VTI_RVOT_ | NR | mPAP ≥25 mmHg and PCWP ≤15 mmHg | 17 | 13 | 5 | 35 | 57 (39 to 74) | 88 (77 to 98) | 43%
Rajagopalan, 2009^52^ Known pulmonary hypertension (N=52) Fair | S’ | < 10 cm/s | sPAP >75 mmHg | 10 | 5 | 2 | 15 | 67 (43 to 90) | 88 (73 to 100) | 47%

CHD = congenital heart disease; CI = confidence interval; cm/s = centimeters per second; CTD = connective tissue disease; FAC = fractional area change; FN = false negative; FP = false positive; JVP = jugular venous pressure; LVEDP = left ventricular end-diastolic pressure; mmHg = millimeter of mercury; mPAP = mean pulmonary artery pressure; MPI = myocardial performance index; NR = not reported; NT-proBNP = N-terminal pro-B-type natriuretic peptide; PAH = pulmonary arterial hypertension; PAT = pulmonary acceleration time; PCWP = pulmonary capillary wedge pressure; PH = pulmonary hypertension; PPH = primary pulmonary hypertension; PVR = pulmonary vascular resistance; RA = right atrium; RIMP = right index of myocardial performance; RV = right ventricle; RVH = right ventricular hypertrophy; RVMPI = right ventricular myocardial performance index; S’ = tricuspid lateral annular systolic velocity; sPAP = systolic pulmonary artery pressure; SSc = systemic sclerosis; TAPSE = tricuspid annular plane systolic excursion; TG = tricuspid gradient; TN = true negative; TP = true positive; TRV = tricuspid regurgitant jet velocity; VSD = ventricular septal defect; VTI_RVOT_ = velocity-time integral of right ventricular outflow tract; WU = Wood unit

Six studies used a variable estimate of RAP (based on inferior vena cava size and inspiratory variation or jugular venous pressure) to calculate sPAP;29,32,38,40,51,83 five studies calculated sPAP using a fixed value for RAP;37,50,59,60,78 and eight studies used TG or TRV.30,34,36,39,42,46,75,77

Eleven of these studies were of patients with systemic sclerosis (or other collagen vascular disease) with suspected PAH based on symptoms.30,32,36,37,39,40,46,50,59,77,78 Four studies evaluated liver transplant candidates;29,38,51,60 two studies included patients with sickle cell disease;34,75 and two studies had patients referred for evaluation of suspected PAH without a single high-risk condition.42,83

Sensitivity of estimates ranged from 58 to 100 percent, while specificity estimates ranged from 55 to 98 percent. The paired sensitivity and specificity values are shown in Figure 6 in receiver operating curve space. The studies with the greatest degree of verification bias (large proportion of test-negative patients with no RHC verification of disease status) tend to have both high specificity and sensitivity estimates. Four studies of liver transplant candidates were the only ones to have complete RHC verification, and these studies had sensitivity estimates from 62 to 100 percent and specificity estimates from 82 to 98 percent.29,38,51,60

Figure 6 Summary sensitivity and specificity values for echocardiography sPAP diagnosis of PH

CI = confidence interval

Figure 6. Summary sensitivity and specificity values for echocardiography sPAP diagnosis of PH. This figure presents paired sensitivity and specificity values in a summary receiver operating characteristic (SROC) curve. The studies with the greatest degree of verification bias (large proportion of test-negative patients with no RHC verification of disease status) tend to have both high specificity and sensitivity estimates. Four studies of liver transplant candidates were the only ones to have complete RHC verification, and these studies had sensitivity estimates from 62 to 100 percent and specificity estimates from 82 to 98 percent.

Meta-analysis of the 19 studies yielded summary estimates for sensitivity and specificity of 88 percent, with confidence region as shown in Figure 7. There was moderate heterogeneity (I^2^=61.9%). In an effort to explain the between-study variation, we undertook a sensitivity analysis based on features we suspected might account for variation and that had suitable distributions among the studies. The results of the sensitivity analyses are shown in Table 9.

Figure 7 Sensitivity and specificity of echocardiography sPAP for diagnosis of PAH

CI = confidence interval; FN = false negative; FP = false positive; TN = true negative; TP = true positive

Figure 7. Sensitivity and specificity of echocardiography sPAP for diagnosis of PAH. This figure shows the meta-analysis of the 19 studies, which yielded summary estimates for sensitivity and specificity of 88 percent. There was moderate heterogeneity (I2=61.9%).

Table 9 Sensitivity analysis of echocardiography sPAP by study characteristics

Study Characteristic | Number of Studies (Patients) | Summary Sensitivity (95% CI) | Summary Specificity (95% CI) | I^2^
Prevalence
Less than 15% | 10 (1638) | 90.6 (84.9 to 94.2) | 90.8 (85.2 to 94.4) | 0
15% or more | 9 (821) | 83.7 (71.8 to 91.2) | 83.6 (71.7 to 91.1) | 62.7%
Diagnosis
Liver transplant | 4 (432) | 79.7 (72.5 to 85.4) | 93.8 (91.1 to 95.8) | 0
Systemic sclerosis | 10 (1474) | 88.7 (82.2 to 93.1) | 89.7 (83.6 to 93.7) | 52.5%
Other (SSD, CVD) | 5 (553) | 90.3 (71.8 to 97.2) | 73.2 (42.7 to 90.9) | 73.6%
RAP Method
None or fixed | 13 (1891) | 89.9 (84.5 to 93.6) | 88.9 (83.1 to 92.9) | 56.1%
Variable | 6 (561) | 81.4 (70.1 to 89.1) | 85.0 (75.3 to 91.4) | 63.8%

CI = confidence interval; CVD = collagen vascular disease; RAP = right atrial pressure; sPAP = systolic pulmonary artery pressure; SSD = sickle cell disease

Studies with lower prevalence of PH (less than 15% of study subjects) showed greater homogeneity than studies with higher prevalence of PH. These 10 low-prevalence studies included the four studies of liver transplant patients (which had complete verification of test-negative subjects) and 6 studies that had high degree of verification bias. The studies among liver transplant patients had no important heterogeneity compared with 10 studies of systemic sclerosis patients or studies in patients with other diagnoses. The method of correction for RAP (fixed or none versus variable estimate) did not explain between-study heterogeneity.

Seven studies (three good quality, three fair, 1 poor) evaluated the echocardiographic estimation of PVR using TRV/VTI_RVOT_ against RHC diagnosis of elevated PVR (Figure 8).31,41,52,55,65,69,74 Three of these studies included patients with known PH.41,52,55 Two studies used a threshold for PVR much higher than that used for diagnosis (8 Wood units versus 2 Wood units)65,69 with the goal of distinguishing more severe PAH; these studies also used a higher test threshold of 0.2 and 0.38 compared with 0.14 to 0.175. Sensitivity ranged from 57 to 94 percent, while specificity ranged from 57 to 100 percent.

Figure 8 Sensitivity and specificity of TRV/VTI_RVOT_ for diagnosis of PAH

CI = confidence interval; FN = false negative; FP = false positive; TN = true negative; TP = true positive

Figure 8. Sensitivity and specificity of TRV/VTIRVOT for diagnosis of PAH. This figure presents the sensitivity and specificity for seven studies that evaluated the echocardiographic estimation of PVR using TRV/VTIRVOT against RHC diagnosis of elevated PVR. Sensitivity ranged from 57 to 94 percent, while specificity ranged from 57 to 100 percent.

##### Echocardiographic Parameters by Diagnostic Group

Fifteen studies reported data on the mean (or median) and standard deviation (or interquartile range) for specific echocardiographic parameters for patients with and without PAH (Table 10). Two of these studies reported echocardiographic values at baseline for prospectively identified incident cases of PAH.27,35 In one study, the diagnostic categories distinguished between primary PAH and chronic thromboembolic pulmonary hypertension.48

Table 10 Echocardiographic parameter values by diagnostic group

Study Population (N) Quality | Echocardiographic Parameter | Criteria for Verification by RHC | Reference Diagnostic Criterion | Patients With PAH | | Patients Without PAH | | P-value
Study Population (N) Quality | Echocardiographic Parameter | Criteria for Verification by RHC | Reference Diagnostic Criterion | | | | | P-value
Study Population (N) Quality | Echocardiographic Parameter | Criteria for Verification by RHC | Reference Diagnostic Criterion | N | Mean (SD) | N | Mean (SD) | P-value
Ruan, 2007^56^ Known PAH and healthy controls (N=180) Fair | FAC | NR (case-control design) | NR | 70 | 19 (10) | 35 | 53 (10) | NR
Fukuda, 2011^72^ Patients with known PH (N=67) Fair | FAC | NR (case-control design) | mPAP > 25 mmHg | 45 | 37 (13) | 22 | 51 (1) | <0.001
Rajagopalan, 2009^52^ Known pulmonary hypertension (N=52) Fair | FAC | NR (case-control design) | | 32 | 31 (12) | 15 | 52 (5) | <0.05
Bonderman, 2011^26^ Referred for evaluation of suspected PAH; more than half had NYHA III/IV symptoms (N=372) Good | RA size | sPAP ≥36 mmHg | mPAP >25 mmHg, PCWP <15 mmHg | 64 | 58.7 (10.9) | 57 | 59.1 (11.5) | 0.87
Hachulla, 2005^36^ SSc patients; some symptomatic (N=599) Poor | RA size (transverse) | NR (case-control design) | mPAP ≥25 mmHg rest or ≥30 mmHg with exercise and PCWP ≤15 mmHg | 18 | 38.7 (8.3) | 548 | 34.3 (7.0) | 0.01
Hachulla, 2005^36^ SSc patients; some symptomatic (N=599) Poor | RA size (longitudinal) | NR (case-control design) | mPAP ≥25 mmHg rest or ≥30 mmHg with exercise and PCWP ≤15 mmHg | 18 | 48.3 (7.2) | 548 | 42.1 (7.2) | 0.0001
Fukuda, 2011^72^ Patients with known PH (N=67) Fair | RIMP | NR (case-control design) | mPAP >25 mmHg | 45 | 0.4 (0.1) | 22 | 0.2 (0.1) | <0.001
Tei, 1996^61^ Known PPH and health controls (N=53) Poor | RIMP | NR (case-control design) | NR | 26 | 0.89 (0.25) | 37 | 0.28 (0.04) | <0.001
Gialafos, 2008^71^ SSc patients. Some were symptomatic (N=106) Fair | RIMP | sPAP >40 mmHg (18/37 patients verified by RHC) | NR | 37 | 0.41 (0.03) | 69 | 0.37 (0.02) | <0.001
Bonderman, 2011^26^ Referred for evaluation of suspected PAH; more than half had NYHA III/IV symptoms (N=372) Good | RV size | sPAP ≥36 mmHg | mPAP >25 mmHg, PCWP <15 mmHg | 64 | 44 (9.2) | 57 | 38.2 (6.9) | <0.001
Hachulla, 2005^36^ SSc patients; some symptomatic (N=599) Poor | RV size | NR (case-control design) | mPAP ≥25 mmHg rest or ≥30 mmHg with exercise and PCWP ≤15 mmHg | 18 | 33.0 (5.9) | 548 | 30.0 (6.6) | 0.061
Rajagopalan, 2009^52^ Known pulmonary hypertension (N=52) Fair | RV size (end-diastolic area) | NR (case-control design) | | 32 | 27 (11) | 15 | 20 (4) | <0.05
Rajagopalan, 2009^52^ Known pulmonary hypertension (N=52) Fair | RV size (end systolic area) | NR (case-control design) | | 32 | 19 (9) | 15 | 9 (3) | <0.05
Ruan, 2007^56^ Known PAH and healthy controls (N=180) Fair | RV size | NR (case-control design) | NR | 70 | 28 (9) | 35 | 14 (6) | NR
Fukuda, 2011^72^ Patients with known PH (N=67) Fair | S′ | NR (case-control design) | mPAP >25 mmHg | 45 | 11.8 (2.9) | 22 | 14.1 (2.4) | <0.001
Rajagopalan, 2009^52^ Known pulmonary hypertension (N=52) Fair | S′ | NR | NR | 32 | 10.9 (2.9) | 15 | 13.8 (2.8) | <0.01
Ruan, 2007^56^ Known PAH and healthy controls (N=180) Fair | S′ | NR (case-control design) | NR | 70 | 8 (3) | 35 | 15.8 (5.5) | <0.05
Bonderman, 2011^26^ Referred for evaluation of suspected PAH; more than half had NYHA III/IV symptoms (N=372) Good | sPAP | sPAP ≥36 mmHg | mPAP >25 mmHg PCWP <15 mmHg | 64 | 82.6 (24.3) | 57 | 55.2 (16.3) | <0.001
Ruan, 2007^56^ Known PAH and healthy controls (N=180) Fair | sPAP | NR (case-control design) | NR | 70 | 73 (6) | 35 | 21 (6) | NR
Torregrosa, 2001^60^ Liver transplant candidates (N=94) Fair | sPAP | NA (all patients had RHC) | mPAP ≥25 mmHg PVR >120 dyne*sec/cm^5^ | 5 | 54 (15) | 102 | 36 (5) | <0.001
Fukuda, 2011^72^ Patients with known PH (N=67) Fair | sPAP | NR (case-control design) | mPAP >25 mmHg | 45 | 67 (23) | 22 | 20 (10) | 0.0001
Fitzgerald, 2012^75^ Adults with SCD (N=75) Poor | TRV | TRV ≥2.5 | mPAP ≥25 mmHg, PCWP ≤15 mmHg | 9 | 2.7 (0.16) | 16 | 3.1 (0.68) | 0.12
Hammerstingl, 2012^76^ Patients with PH undergoing RHC (N=155) Fair | sPAP | sPAP >30 mmHg, all patients had RHC | mPAP ≥25 mmHg, PCWP ≤15 mmHg | 36 | 58.3 (23.6) | 119 | 49.9 (14.2) | 0.009
Hammerstingl, 2012^76^ Patients with PH undergoing RHC (N=155) Fair | RVDs | sPAP >30 mmHg, all patients had RHC | mPAP ≥25 mmHg, PCWP ≤15 mmHg | 36 | 2.4 (1.2) | 119 | 2.4 (1.1) | 0.8
Hammerstingl, 2012^76^ Patients with PH undergoing RHC (N=155) Fair | RVDd | sPAP >30 mmHg, all patients had RHC | mPAP ≥25 mmHg, PCWP ≤15 mmHg | 36 | 3.4 (1.6) | 119 | 3.3 (1.3) | 0.88
Fukuda, 2011^72^ Patients with known PH (N=67) Fair | TAPSE | NR (case-control design) | mPAP >25 mmHg | 45 | 18 (4) | 22 | 21 (3) | <0.001
Cevik, 2012^74^ Children with CHD and healthy controls (N=70) Fair | RVMPI/RIMP | NA (all patients had CHD) | mPAP ≥25 mmHg, PCWP ≤15 mmHg | 30 | 0.45 (0.14) | 40 | 0.35 (0.08) | <0.001
Cevik, 2012^74^ Children with CHD and healthy controls (N=70) Fair | S′ (Ts’) | NA (all patients had CHD) | mPAP ≥25 mmHg, PCWP ≤15 mmHg | 30 | 0.13 (0.09–0.58) | 40 | 0.13 (0.10–0.18) | 0.42
Cevik, 2012^74^ Children with CHD and healthy controls (N=70) Fair | TAPSE | NA (all patients had CHD) | mPAP ≥25 mmHg, PCWP ≤15 mmHg | 30 | 1.96 (1.03–3.22) | 40 | 2.53 (1.1–4.25) | 0.10
Cevik, 2012^74^ Children with CHD and healthy controls (N=70) Fair | sPAP/VTI_RVOT_ | NA (all patients had CHD) | mPAP ≥25 mmHg, PCWP ≤15 mmHg | 30 | 1.3 (0.0–8.8) | 40 | 0.5 (0.0–1.2) | <0.001
Cevik, 2012^74^ Children with CHD and healthy controls (N=70) Fair | sPAP/VTI_RVOT_ | NA (all patients had CHD) | mPAP ≥25 mmHg, PCWP ≤15 mmHg | 30 | 1.0 (0.0–9.0) | 40 | 0.6 (0.01–1.0) | 0.015
Sanli, 2012^79^ Children with unrepaired CHD with or without PAH and healthy controls (N=70) Fair | RVMPI/RIMP | NA (all patients had RHC) | mPAP ≥25 mmHg, PCWP ≤15 mmHg | 30 | 0.30 (0.10) | 20 | 0.22 (0.03) | <0.001
Sanli, 2012^79^ Children with unrepaired CHD with or without PAH and healthy controls (N=70) Fair | TAPSE | NA (all patients had RHC) | mPAP ≥25 mmHg, PCWP ≤15 mmHg | 30 | 1.90 (0.24) | 20 | 2.42 (0.21) | <0.0001
Sanli, 2012^79^ Children with unrepaired CHD with or without PAH and healthy controls (N=70) Fair | RVD/RV size | NA (all patients had RHC) | mPAP ≥25 mmHg, PCWP ≤15 mmHg | 30 | 4.40 (0.74) | 20 | 4.15 (0.62) | >0.05
Takatsuki, 2012^82^ Children with iPAH (N=51) and healthy controls (N=51) (total N=102) Fair | RVDd | NA (case-control design; 88% had RHC) | mPAP ≥25 mmHg, PCWP ≤15 mmHg | 51 | 23.5 (6.0) | 51 | 18.1 (4.9) | <0.001
Takatsuki, 2012^82^ Children with iPAH (N=51) and healthy controls (N=51) (total N=102) Fair | RVMPI | NA (case-control design; 88% had RHC) | mPAP ≥25 mmHg, PCWP ≤15 mmHg | 51 | 0.63 (0.30) | 51 | 0.21 (0.10) | <0.001
Takatsuki, 2012^82^ Children with iPAH (N=51) and healthy controls (N=51) (total N=102) Fair | TRV | NA (case-control design; 88% had RHC) | mPAP ≥25 mmHg, PCWP ≤15 mmHg | 51 | 4.1 (0.8) | 51 | 2.2 (0.2) | <0.001
Takatsuki, 2012^82^ Children with iPAH (N=51) and healthy controls (N=51) (total N=102) Fair | S′ | NA (case-control design; 88% had RHC) | mPAP ≥25 mmHg, PCWP ≤15 mmHg | 51 | 11.3 (2.4) | 51 | 13.6 (2.8) | <0.001
Ruan, 2007^56^ Known PAH and healthy controls (N=180) Fair | TRV/VTI_RVOT_ | NA (case-control design) | NR | 70 | 0.66 (0.13) | 35 | 0.13 (0.11) | <0.01
Frea, 2011^35,a^ SSc patients with no signs or symptoms of PAH (N=76) Fair | FAC | TRV≥3m/s or sPAP≥40mmHg | mPAP ≥25 mmHg, PCWP ≤15 mmHg | 4 | 41.25 (2.22) | 34 | 43.7 (4.5) | 0.29
Frea, 2011^35,a^ SSc patients with no signs or symptoms of PAH (N=76) Fair | RIMP | TRV ≥3 m/s or sPAP ≥40 mmHg | mPAP ≥25 mmHg, PCWP ≤15 mmHg | 4 | 0.32 (0.16) | 34 | 0.26 (0.07) | 0.14
Frea, 2011^35,a^ SSc patients with no signs or symptoms of PAH (N=76) Fair | RV size | TRV ≥3 m/s or sPAP ≥40 mmHg | mPAP ≥25 mmHg, PCWP ≤15 mmHg | 4 | 35.2 (30) | 34 | 33 (3.5) | 0.24
Frea, 2011^35,a^ SSc patients with no signs or symptoms of PAH (N=76) Fair | TRV/VTI_RVOT_ | TRV ≥3 m/s or sPAP ≥40 mmHg | mPAP≥25mmHg, PCWP≤15mmHg | 4 | 0.157 (0.033) | 34 | 0.122 (0.022) | 0.01
Frea, 2011^35,a^ SSc patients with no signs or symptoms of PAH (N=76) Fair | TAPSE | TRV ≥3 m/s or sPAP ≥40 mmHg | mPAP ≥25 mmHg, PCWP ≤15 mmHg | 4 | 23 (1.63) | 34 | 22.3 (2.19) | 0.54
Allanore, 2008^27,a^ SSc patients with echocardiography sPAP <40 mmHg and no NYHA III/IV symptoms (N=101) Good | sPAP | sPAP >40 mmHg, DLCO <50% predicted without pulmonary fibrosis or unexplained dyspnea, negative CT, D-dimer | mPAP ≥25 mmHg, PCWP ≤15 mmHg | 8 | 38.2 (9.4) | 93 | 31.2 (5.9) | 0.001
Nakayama, 1998^48,b^ Patients with known, symptomatic CTEPH or PPH (N=35) Fair | mPAP | NA (all patients had RHC) | NR but includes negative V/Q scan | 19 | 41 (10) | 16 | 54 (9)

CTEPH = chronic thromboembolic pulmonary hypertension; DLCO = diffusion capacity of the lung for carbon monoxide; iPAH = idiopathic pulmonary arterial hypertension; mmHg = millimeter of mercury; mPAP = mean pulmonary artery pressure; MPI = myocardial performance index; NT-proBNP = N-terminal pro-B-type natriuretic peptide; PAH = pulmonary arterial hypertension; PH = pulmonary hypertension; PPH = primary pulmonary hypertension; PVR = pulmonary vascular resistance; RA = right atrium; RHC = right heart catheterization; RIMP = right index of myocardial performance; RV = right ventricle; RVD = right ventricular dysfunction; RVDd = right ventricular dysfunction (diastolic); RVDs = right ventricular dysfunction (systolic); sPAP = systolic pulmonary artery pressure; SD = standard deviation; SSc = systemic sclerosis; TRV = tricuspid regurgitant jet velocity; V/Q = ventilation perfusion scan; VSD = ventricular septal defect; VTI_RVOT_ = velocity-time integral of right ventricular outflow tract

a Studies that assessed baseline NT-proBNP as predictors of future development of PAH.

b Study attempted to distinguish primary PAH from CTEPH (rather than no PAH).

In the two studies that examined echocardiographic predictors of later development of PAH, TRV/VTI_RVOT_ and sPAP at baseline showed statistically significant differences among those who later developed PAH compared with those who did not (Table 10). Other parameters examined, including FAC, RIMP, RV size and TAPSE, failed to show statistically significant differences; however, the number of cases in this study was small (n=4), suggesting this analysis lacks sensitivity. Likewise the number of parameters examined for association is large relative to the number of cases, suggesting the possibility of finding significant associations by chance.

Thirteen studies evaluated concurrent echocardiography measurement with diagnosis of PAH and provided data on seven different echocardiographic parameters: sPAP (or TRV), RIMP, RV size, RA size, S′, TAPSE, TRV/VTI_RVOT_ and FAC. Seven of the studies used a case-control design; four used elevated sPAP by echocardiography to select patients for diagnostic verification; three studies verified all participants’ diagnosis with RHC:

- For FAC, three case-control studies showed reasonably large differences, statistically significant in both studies that reported a statistical comparison.
- For RA size, findings in two studies were inconsistent: one case-control study reported statistically significant differences, but a cohort study found no difference.
- For RIMP, all six studies reported statistically significant differences.
- For RV size, three of eight studies reported statistically significant differences, four did not detect a difference, and one study did not report a statistical test for differences.
- For S′, four of five studies reported statistically significant differences.
- For TAPSE, two of three studies reported statistically significant differences.
- For TRV/VTI_RVOT_ or the related sPAP/VTI_RVOT_, both studies showed statistically significant differences.

Four studies indicated large differences in echocardiography sPAP between patients with PAH and those without PAH with differences in means ranging from 18 to 52 mmHg. These differences, while highly significant, reflect incorporation bias since the diagnostic classification is based on mPAP, which is highly correlated with sPAP.

##### Accuracy and Precision of Echocardiography Versus RHC

Twenty-eight studies reported the correlation or agreement between echocardiographic measurements and corresponding hemodynamic parameters measured at RHC (Table 11). The correlation coefficient between echocardiography sPAP and RHC sPAP ranged from 0.15 to 0.96. Two studies reported correlation of echocardiography sPAP with both simultaneous and nonconcurrent RHC; in each case, correlations were improved when echocardiography was performed simultaneously with RHC; however, the improvement in correlation was only 0.03 to 0.06.

Table 11 Correlation of echocardiographic parameters with RHC in PAH

Study Population (N) Quality | Echocardiographic Parameter | Measurement Details | RHC Parameter | Total N (N Not Estimable) | Correlation (p-Value) | Bias (SD)
Fukuda, 2011^72^ Patients with known PH (N=67) Fair | FAC | (RV end-diastolic area – RV end-systolic area)/RV end-diastolic area * 100% | mPAP | 45 | −0.47 (0.001)
Fukuda, 2011^72^ Patients with known PH (N=67) Fair | FAC | (RV end-diastolic area – RV end-systolic area)/RV end-diastolic area * 100% | PVR (Fick) | 45 | −0.46 (0.002)
Selimovic, 2007^57^ Patients with suspected pulmonary vascular disease; 37 of 42 NYHA III/IV (N=42) Good | mPAP | PADP + 0.33(PASP – PADP) | mPAP | 56 (4) | 0.91 (0.04) | −2.0 (7.2)
Selimovic, 2007^57^ Patients with suspected pulmonary vascular disease; 37 of 42 NYHA III/IV (N=42) Good | mPAP | Simultaneous with RHC | mPAP | 20 (0) | 0.95 (0.31) | 1.4 (5.8)
Selimovic, 2007^57^ Patients with suspected pulmonary vascular disease; 37 of 42 NYHA III/IV (N=42) Good | sPAP | 4 * TRV^2^ + RAP (5, 10, 15) | sPAP | 56 (4) | 0.88 (0.3) | −1.7 (12.3)
Tian, 2011^62^ Suspected PH based on symptoms (N=42) Fair | mPAP | | mPAP | 42 (0) | 0.88(0.0001) | −5.7 (0.84)
Vonk, 2007^66^ Connective tissue diseases; one-third NYHA III/IV (N=98) Fair | RIMP | | mPAP | 35 (2) | 0.46 (0.01)
Fukuda, 2011^72^ Patients with known PH (N=67) Fair | RIMP | | mPAP | 45 (0) | −0.21 (0.174)
Fukuda, 2011^72^ Patients with known PH (N=67) Fair | RIMP | | PVR (Fick) | 45 (0) | −0.26 (0.12)
Vonk, 2007^66^ Connective tissue diseases; one-third NYHA III/IV (N=98) Fair | RIMP | | PVR (TD) | 35 (2) | 0.33 (0.08)
Fukuda, 2011^72^ Patients with known PH (N=67) Fair | RIMP | | PVR (Fick) | 45 (0) | −0.26 (0.12)
Cevik, 2012^74^ Children with CHD (N=30) and healthy controls (N=40) (total N=70) Fair | RVMPI | | sPAP | 30 (NR) | 0.54 (0.002)
Cevik, 2012^74^ Children with CHD (N=30) and healthy controls (N=40) (total N=70) Fair | RVMPI | | mPAP | 30 (NR) | 0.53 (0.003)
Fukuda, 2011^72^ Patients with known PH (N=67) Fair | S′ | | mPAP | 45 (0) | −0.39 (0.009)
Fukuda, 2011^72^ Patients with known PH (N=67) Fair | S′ | | PVR (Fick) | 45 | −0.41 (0.013)
Dahiya, 2010^31^ Referred for evaluation of suspected PH; all patients had dyspnea (N=114) Good | TRV/VTI_RVOT_ | | PVR (TD) | 50 | 0.77 (0.001) | 1.8 (3.3)
Lindqvist, 2011^41^ Patients with PH undergoing RHC (N=30) Fair | TRV/VTI_RVOT_ | | PVR (TD) | 25 (5) | 0.78 (0.001) | 6.1 (4.0)
Rajagopalan, 2009^52^ Known pulmonary hypertension (N=52) Fair | TRV/VTI_RVOT_ | | PVR (Fick) | 52 | 0.73 (0.001) | 0 (4.3)
Roule, 2010^55^ Known PH (N=37) Good | TRV/VTI_RVOT_ | | PVR (TD) | 37 (NR) | 0.76 (0.0001) | 0 (1.9)
Vlahos, 2008^65^ Known or suspected pulmonary hypertension (N=12) Poor | TRV/VTI_RVOT_ | | PVR (Fick) | 12 (0) | 0.843 (NR)
Ajami, 2011^69^ Children & young adults with congenital heart disease referred for RHC (N=20) Good | TRV/VTI_RVOT_ | | PVR (Fick) | 20 (0) | 0.73 (NR)
Rajaram, 2012^77^ CTD suspected of PH based on symptoms or screening tests (N=81) Fair | TG | 4 * TRV^2^ | mPAP | 81 (NR) | 0.84 (0.001)
Rajaram, 2012^77^ CTD suspected of PH based on symptoms or screening tests (N=81) Fair | TG | 4 * TRV^2^ | PVR | 81 (NR) | 0.76 (0.001)
Arcasoy, 2003^83^ Advanced lung disease, undergoing evaluation for lung transplantation (N=374) Good | sPAP | 4 * TRV^2^ + RAP | sPAP | 166 (208) | 0.69 (<0.0001)
Denton, 1997^32^ SSc patients suspected of PAH, most due to reduced DLCO (N=93) Fair | sPAP | 4 * TRV^2^ + JVP | sPAP | 20 (13) | 0.83 (0.001) | 11.4 (9.8)
Farber, 2011^9^ Patients with PAH (N=1883) Fair | sPAP | 4 * TRV^2^ + RAP | sPAP | 1360 (NR) | 0.56 (0.001)
Hammerstingl, 2012^76^ Patients with PH undergoing RHC (N=155) Fair | sPAP | | mPAP | 155 (NR) | 0.43 (<0.0001)
Hammerstingl, 2012^76^ Patients with PH undergoing RHC (N=155) Fair | sPAP | | sPAP | 155 (NR) | 0.15 (0.06)
Hsu, 2008^37^ SSc patients with dyspnea or other clinical features suggestive of PAH (N=49) Good | sPAP | 4 * TRV^2^ + 10 | sPAP | 49 (NR) | 0.71 (NR)
Fisher, 2009^33^ Patients undergoing RHC for known or suspected PAH; symptoms not described (N=65) Good | sPAP | 4 * TRV^2^ + RAP | sPAP | 59 (NR) | 0.66 (0.001) | −0.6 (20)
Kovacs, 2010^40^ Patients with CVD some with symptoms (N=52) Good | sPAP | 4 * TRV^2^ + RAP | sPAP | 28 (9) | | 0.3 (7.6)
Nogami, 2009^49^ Suspected pulmonary hypertension; all patients symptomatic (N=29) Good | sPAP | 4 * TRV^2^ + RAP (5, 15) | sPAP | 20 (0) | 0.86 (0.01) | −5.9 (14.1)
Rich, 2011^53^ Patients with both RHC and Doppler echo (N=183) Good | sPAP | 4 * TRV^2^ + RAP (5, 10, 15 or 20) | sPAP | 160 (EXCL) | 0.68 (0.001) | 2.2 (18.6)
Rich, 2011^53^ Patients with both RHC and Doppler echo (N=183) Good | sPAP | With simultaneous RHC | sPAP | 23 (EXCL) | 0.71 (0.01) | 8.0 (8.8)
Roeleveld, 2005^54^ Known PH (N=47) Fair | sPAP | 4 * TRV^2^ + RAP (5, 10, 15) | sPAP | 35 (9) | 0.375 (0.026) | −5 (30.1)
Roeleveld, 2005^54^ Known PH (N=47) Fair | sPAP | With simultaneous RHC | sPAP | 22 (1) | 0.94 (0.69) | 0.7 (7.8)
Selby, 2012^80^ HIV-infected patients (N=422) Fair | sPAP | 4 * TRV^2^ + RAP | sPAP | 76 (NR) | 0.49 (<0.0001) | 1.75 (7.0)
Tian, 2011^62^ Suspected PH based on symptoms (N=42) Fair | sPAP | 4 * TRV^2^ + RAP (4, 10, 14) | sPAP | 42 (EXCL) | 0.96 (0.0001) | −1.8 (1.8)
Vonk, 2007^66^ Connective tissue diseases. One-third NYHA III/IV (N=98) Fair | sPAP | 4 * TRV^2^ + RAP | sPAP | 35 (0) | NR (0.001)
Willens, 2008^67^ Patients with known PH and elevated sPAP and controls with CHF and elevated sPAP (N=47) Fair | sPAP | 4 * TRV^2^ + RAP | sPAP | 44 (3) | 0.75 (0.001)
Rajagopalan, 2009^52^ Known pulmonary hypertension (N=52) Fair | sPAP | 4 * TRV^2^ + RAP | sPAP | 32 (0) | 0.87 (0.001)
Rajagopalan, 2009^52^ Known pulmonary hypertension (N=52) Fair | S′ | 4 * TRV^2^ + RAP | PVR (Fick) | 32 (0) | −0.79 (<0.0001)
Rajagopalan, 2009^52^ Known pulmonary hypertension (N=52) Fair | S′ | 4 * TRV^2^ + RAP | CO | 32 (0) | 0.78 (<0.001)
Rajagopalan, 2009^52^ Known pulmonary hypertension (N=52) Fair | S′ | 4 * TRV^2^ + RAP | TG | 32 (0) | 0.72 (<0.001)
Murata, 1997^47^ SSc patients. Symptoms not described, but most had reduced DLCO (N=135) Fair | sPAP | 4 * TRV^2^ + 10 | sPAP | 19 (6) | 0.41 (NR) | −0.53 (12.1)
Fukuda, 2011^72^ Patients with known PH (N=67) Fair | TAPSE | Total excursion of tricuspid annulus during systole | mPAP | 45 (0) | −0.33 (0.027)
Fukuda, 2011^72^ Patients with known PH (N=67) Fair | TAPSE | Total excursion of tricuspid annulus during systole | PVR (Fick) | 45 (0) | −0.49 (0.002)
Condliffe, 2011^30^ SSc patients with suspected PAH; symptoms not described (N=89) Fair | TRV | 4 * TRV^2^ | mPAP | 70 (0) | 0.64 (0.001)
Condliffe, 2011^30^ SSc patients with suspected PAH; symptoms not described (N=89) Fair | TRV | 4 * TRV^2^ | PVR (TD) | 70 (0) | 0.76 (0.001)
Fisher, 2009^33^ Patients undergoing RHC for known or suspected PAH; symptoms not described (N=65) Good | TRV | 4 * TRV^2^ | sPAP | 59 (NR) | | −1.8 (18.1)
Fisher, 2009^33^ Patients undergoing RHC for known or suspected PAH; symptoms not described (N=65) Good | CO | 4 * TRV^2^ | CO (TD) | 65 (NR) | 0.74 (<0.001) | −0.1 (1.2)
Fonseca, 2011^34^ Sickle cell disease; symptoms not described (N=80) Fair | TRV | 4 * TRV^2^ | sPAP | 26 (0) | 0.77 (0.001)
Mourani, 2008^45^ Children under 2 years of age undergoing RHC for chronic lung disease (N=25) Fair | TRV | 4 * TRV^2^ | sPAP | 19 (12) | 0.19 (0.43)
Mukerjee, 2004^46^ SSc patients with suspected PAH, symptoms of exercise limitation and reduced DLCO (N=137) Fair | TRV | TG calculated from TRV using “standard templates” | sPAP | 137 (NR) | 0.67 (NR)
Roule, 2010^55^ Known PH (N=37) Good | TRV | 4 * TRV^2^ | sPAP | 37 (0) | 0.8 (NR)

CO = cardiac output; EXCL = excluded from study; JVP = jugular venous pressure; mPAP = mean pulmonary artery pressure; MPI = myocardial performance index; NR = not reported; NT-proBNP = N-terminal pro-B-type natriuretic peptide; PAH = pulmonary arterial hypertension; PADP = pulmonary artery diastolic pressure; PASP = pulmonary artery systolic pressure; PH = pulmonary hypertension; PPH = primary pulmonary hypertension; PVR = pulmonary vascular resistance; RAP = right atrial pressure; RHC = right heart catheterization; RIMP = right index of myocardial performance; RV = right ventricle; SD = standard deviation; sPAP = systolic pulmonary artery pressure; SSc = systemic sclerosis;

TAPSE = tricuspid annular plane systolic excursion; TG = tricuspid gradient; TRV = tricuspid regurgitant jet velocity; VSD = ventricular septal defect; VTI_RVOT_ = velocity-time integral of right ventricular outflow tract

Bias in measurement was estimated by examining the difference between two tests measured on the same scale using the method of Bland and Altman. In nine studies comparing sPAP values, the average bias varied between a 5.9 mmHg underestimate and an 11.4 mmHg overestimate by echocardiography. The standard deviation of the bias measurements ranged from 1.8 to 30.1, with a median of 9.3. With a standard deviation of this magnitude, one would expect about 70 percent of echocardiography sPAP readings to fall within 10 mmHg of RHC sPAP; however, the large REVEAL registry9 found that only 39.8 percent of echocardiographic estimates of sPAP were within 10mmHg of same-day RHC-measured sPAP, corresponding to a standard deviation of approximately 19 mmHg. The remaining 60 percent were approximately equally divided between overestimates (greater than 10 mmHg) and underestimates (greater than 10 mmHg). Three additional studies reported the percentage of patients in which echocardiography sPAP and RHC sPAP readings were within 10 mmHg of each other. Two studies found this to be 48 percent,33,83 which would suggest a standard deviation of approximately 15 mmHg. The third study reported 80 percent,80 which would suggest a standard deviation of approximately 7.8. In one study, divergence between echocardiography and RHC was greater than 20 mmHg in 28 percent of patients and greater than 30 mmHg in 9 percent of patients,83 both suggesting a standard deviation of approximately 18. These estimates assume a normal distribution and a bias of zero (Table 12).

Table 12 Further data on accuracy of echocardiographic estimates of sPAP compared with RHC, described as percentage of patients within a specified threshold

Study | Percentage of Echocardiographic Estimates Within Threshold | | | Standard Deviation
Study | 10 mmHg | 20 mmHg | 30 mmHg | Estimated | Reported
Farber, 2011^9^ | 39.8% | – | – | 19.2 | NR
Fisher, 2009^33^ | 48% | – | – | 15.4 | 20
Arcasoy, 2003^83^ | 48% | – | – | 15.4 | NR
Arcasoy, 2003^83^ | – | 72% | – | 18.5 | NR
Arcasoy, 2003^83^ | – | – | 91% | 17.6 | NR
Selby, 2012^80^ | 80% | – | – | 7.8 | 7.0

mmHg = millimeter of mercury; NR = not reported

Four studies reported correlation between echocardiography transtricuspid gradient and sPAP, with estimates ranging from 0.19 to 0.80. The low outlier was a small study of young children with chronic lung disease. One other study found negligible bias but a large standard deviation of difference between echocardiography and RHC measures.33 Two additional studies correlated TG and mPAP with estimates of 0.64 and 0.84, respectively.30,77

Six studies correlated TRV/VTI_RVOT_ with PVR by RHC. Correlation coefficients indicated strong correlation ranging from 0.73 to 0.84, with bias ranging from 0 to 6.1, and standard deviations ranging from 1.9 to 4.3 Wood units.

Two studies reported strong correlations between echocardiographic estimates of mPAP with RHC-measured mPAP. Correlation coefficients were 0.88 and 0.91 but increased to 0.95 when echocardiography was simultaneous with RHC. The estimates of bias of a 2 and 5.7 mmHg underestimate improved to a 1.4 mmHg overestimate when echocardiography was performed simultaneously with RHC; the standard deviations of difference between echocardiography and RHC ranged from 0.84 to 7.2.

Low to moderate correlations were observed between RIMP and mPAP, RIMP and PVR, TAPSE and mPAP, FAC and mPAP, and FAC and PVR. Two studies found a strong correlation between TG and PVR.30,77

Two studies correlated S′ with RHC hemodynamic measures and reported moderate to strong correlation of S′ with PVR (Fick), CO, and TG.52,72

### Summary Strength of Evidence for KQ 1

Results for these outcomes and comparisons, along with ratings for strength of evidence are shown in Tables 13–16.

Table 13 Summary strength of evidence for KQ 1: Echocardiography sPAP with NT-proBNP versus echocardiography sPAP in symptomatic patients

Parameter | Number of Studies (Patients) | Domains | | | | Strength of Evidence Effect Estimate (95% CI)
Parameter | Number of Studies (Patients) | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Effect Estimate (95% CI)
Sensitivity | 1 (121) | High | NA | Direct | Imprecise | SOE = Insufficient NT-proBNP >80 pg/mL has a low false-negative rate compared with RHC reference standard; the serial testing study design did not allow for NT-proBNP testing to improve sensitivity beyond that of echo sPAP alone
Specificity | 1 (121) | Moderate | NA | Direct | Imprecise | SOE = Low NT-proBNP ≤80 pg/mL ruled out PAH in 9–16% of patients with elevated echo sPAP ≥36 mmHg
Correlation | 0 (0) | NA | NA | NA | NA | SOE = Insufficient NA
Adverse effects | 0 (0) | NA | NA | NA | NA | SOE = Insufficient NA

CI = confidence interval; echo = echocardiography; NA = not applicable; NT-proBNP = N-terminal pro-B-type natriuretic peptide; PAH = pulmonary arterial hypertension; RHC = right heart catheterization; SOE = strength of evidence; sPAP = systolic pulmonary artery pressure

Table 14 Summary strength of evidence for KQ 1: NT-proBNP compared with RHC

Parameter | Number of Studies (Patients) | Domains | | | | Strength of Evidence Effect Estimate (95% CI)
Parameter | Number of Studies (Patients) | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Effect Estimate (95% CI)
Sensitivity | 3 (198) | Moderate | Inconsistent | Indirect | Imprecise | SOE = Low Range 56% to 100% NT-proBNP has variable sensitivity for diagnosing PAH; uncertain performance for ruling out PAH
Specificity | 3 (198) | Moderate | Inconsistent | Indirect | Imprecise | SOE = Low Range 24% to 95% NT-proBNP has variable specificity; uncertain performance for ruling in PAH
Correlation | 3 (176) | Moderate | Consistent | Indirect | Imprecise | SOE = Moderate Range 0.43 to 0.72 Correlation of NT-proBNP and RHC is only moderate
Adverse effects | 0 (0) | NA | NA | NA | NA | SOE = Insufficient NA

CI = confidence interval; NT-proBNP = N-terminal pro-B-type natriuretic peptide; PAH = pulmonary arterial hypertension; RHC = right heart catheterization; SOE = strength of evidence

Table 15 Summary strength of evidence for KQ 1: TRV/TG/sPAP compared with RHC

Parameter | Number of Studies (Patients) | Domains | | | | Strength of Evidence Effect Estimate (95% CI)
Parameter | Number of Studies (Patients) | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Effect Estimate (95% CI)
Sensitivity | 19 (2459) | Moderate | Consistent | Indirect | Imprecise | SOE = Moderate Range 58% to 100% Echocardiographic estimate of sPAP showed variable sensitivity, with lower prevalence studies finding higher sensitivity
Specificity | 19 (2459) | Moderate | Consistent | Indirect | Imprecise | SOE = Moderate Range 50% to 98% Echocardiographic estimate of sPAP showed variable specificity, with lower prevalence studies finding higher specificity
Correlation | 23 (4217) | Low | Inconsistent | Indirect | Imprecise | SOE = Moderate Range 0.38 to 0.96 Echocardiographic estimate of sPAP showed moderate to strong correlation with RHC and were on average unbiased, but were limited by imprecision and by a significant minority of patients in whom TRV was not measurable
Adverse effects | 0 (0) | NA | NA | NA | NA | SOE = Insufficient NA

CI = confidence interval; PAH = pulmonary arterial hypertension; RHC = right heart catheterization; SOE = strength of evidence; sPAP = systolic pulmonary artery pressure; TG = tricuspid gradient; TRV = tricuspid regurgitant jet velocity

Table 16 Summary strength of evidence for KQ 1: TRV/VTI_RVOT_ compared with RHC

Parameter | Number of Studies (Patients) | Domains | | | | Strength of Evidence Effect Estimate (95% CI)
Parameter | Number of Studies (Patients) | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Effect Estimate (95% CI)
Sensitivity | 6 (196) | Moderate | Consistent | Indirect | Precise | SOE = Moderate Range 89% to 100% Echocardiographic estimate of PVR showed reasonably high sensitivity for ruling in PAH
Specificity | 6 (196) | Moderate | Consistent | Indirect | Imprecise | SOE = Moderate Range 50% to 97% Echocardiographic estimate of PVR showed variable specificity, with better specificity in lower prevalence studies (range, 94% to 97%)
Correlation | 6 (196) | Low | Consistent | Indirect | Precise | SOE = High Range 0.74 to 0.84 Strong correlation between echocardiographic estimates of PVR and PVR by RHC
Adverse effects | 0 (0) | NA | NA | NA | NA | SOE = Insufficient NA

CI = confidence interval; PAH = pulmonary arterial hypertension; PVR = pulmonary vascular resistance; RHC = right heart catheterization; SOE = strength of evidence; TRV = tricuspid regurgitant jet velocity; VTI_RVOT_ = velocity-time integral of right ventricular outflow tract

## KQ 2 Management of PAH

For patients with PAH, what are the comparative effectiveness and safety of (a) echocardiography versus biomarkers and (b) echocardiography versus echocardiography plus biomarkers in managing PAH and on intermediate-term (≤90 days) and long-term (>90 days) patient outcomes ?

### Key Points

- No data are available regarding the comparative effectiveness of echocardiography versus biomarkers or echocardiography versus echocardiography plus biomarkers in the management of PAH or patient outcomes (insufficient strength of evidence).
- Systolic pulmonary artery pressure (sPAP) estimated by echocardiography shows good correlation with sPAP from RHC (low strength of evidence).
- Serum brain natriuretic peptide (BNP) level shows only moderate correlation with these RHC measures: mean pulmonary artery pressure (mPAP) (moderate strength of evidence), pulmonary vascular resistance (low strength of evidence), right atrial pressure (moderate strength of evidence), cardiac index (low strength of evidence), and clinical outcomes such as the 6-minute walk distance (6MWD) test (moderate strength of evidence).
- BNP level shows poor correlation with RHC pulmonary capillary wedge pressure (PCWP) (low strength of evidence).
- BNP level alone is not an accurate surrogate marker for disease severity (high strength of evidence).
- Increase in level of log-transformed BNP is a strong predictor of mortality (moderate strength of evidence).
- Presence of pericardial effusion is also a strong predictor of mortality although there was wide variability in results for this measure (moderate strength of evidence).
- Right atrial (RA) size correlates with increased risk of mortality (moderate strength of evidence).
- Fractional area change (FAC) is a poor predictor of mortality, but results are variable across studies (moderate strength of evidence).
- Serum uric acid level appears to predict mortality (low strength of evidence)
- Tricuspid annular plane systolic excursion (TAPSE) has inconsistent association with mortality (insufficient strength of evidence).
- We found no studies addressing diagnostic thinking efficacy, therapeutic efficacy, or harms (insufficient strength of evidence).

### Description of Included Studies

We identified 99 unique studies involving a total of 8655 patients that evaluated the use of biomarkers or echocardiographic parameters in the management of PAH or as predictors of patient outcomes.6,43,58,68,84–178 Of these studies, 68 were rated good quality, 29 fair quality, and 2 poor quality. Biomarkers evaluated were natriuretic peptides, endothelin-1, uric acid, troponin T, nitric oxide, asymmetric dimethylarginine, cyclic guanosine monophosphate, and D-dimer. Echocardiographic parameters evaluated were right ventricular (RV) size, RA size, FAC, TAPSE, right ventricular index of myocardial performance (RIMP), myocardial performance index (MPI), Tei index, sPAP, mPAP, tricuspid regurgitation (TR) jet, tricuspid regurgitation jet velocity/velocity-time integral right ventricular outflow tract (TRV/VTI_RVOT_), right ventricular ejection fraction (RVEF), right ventricular systolic pressure (RVSP), and pericardial effusion. We found no studies addressing diagnostic thinking efficacy or therapeutic efficacy.

#### Study Characteristics

Table F-2 in Appendix F summarizes the study location, patient population, study size, sex ratio, index test, comparator, type of result reported, and the quality for each study relevant to KQ 2. Of the 95 studies that reported sex, there were a total of 3972 women and 1618 men. Of the 93 studies that reported age, 72 studies included adults,6,58,68,84,85,88–94,96,97,100–104,106–121,124,125,127,128,130–134,137,139–145,147–152,154,156,157,159,160,162,164,166,167,170,171,174,175,178 9 studies included children,87,98,122,129,136,153,172,173,177 and 12 studies included both adults and children.86,99,105,138,146,158,161,163,165,168,169,176 Study locations included Asia (23 studies), Europe (36), United States or Canada (29), Africa (1), Australia/New Zealand (1), South America (1), multiple geographic locations (3), and unreported or unclear setting (5).

We did not find any studies that assessed the comparative effectiveness of echocardiography versus biomarkers or echocardiography versus echocardiography plus biomarkers as outlined in our original Key Question. We did find one recent validation study by Benza et al.179 of a PAH risk calculator that incorporates biomarkers, echocardiographic findings, and clinical assessment to predict survival. Previously, this team had developed the risk calculator based on known prognosticators of survival in patients with PAH. These variables include World Health Organization subgroup demographics (sex and age), renal disease, functional class, vital signs, 6MWD test, BNP level, presence of pericardial effusion, pulmonary function tests, and findings on RHC, each of which were assigned point values based on presence or level. This recent study validated the risk calculator using prospectively collected independent data from patients with newly diagnosed class I PAH and showed good discriminatory ability. This was the only predictive model we found that both incorporated multiple risk factors, including biomarkers and echocardiographic parameters, and was prospectively validated. However, this report does not permit the assessment of the combination of biomarker and echocardiographic data compared with other routine clinical assessment alone.

Because of the lack of data directly addressed in the key question, we instead focus the remainder of this section on the available studies that evaluate the ability of echocardiography or biomarkers to assess the severity of PAH, to predict events such as lung transplantation or death, or to assess a patient’s response to therapy. By evaluating the independent association of biomarkers or echocardiography, one can impute the comparative effectiveness via indirect comparison. The most common biomarker evaluated was BNP (59 studies), followed by uric acid (9), endothelin-1 (6), troponin T (4), nitric oxide (2), cGMP (2) and ANP (1). We found no studies assessing D-dimer or asymmetric dimethylarginine to evaluate their ability to assess severity of disease, response to therapy, or outcome.

Thirty-nine studies evaluated several echocardiographic parameters. These included sPAP (17 studies), RIMP/MPI/Tei (14), RA size (11), pericardial effusion (11), RV size (9), FAC (8), mPAP (8), TAPSE (6), TR jet (4), TRV/VTI_RVOT_ (3), RVEF (2), echocardiography-derived cardiac index (2), and RVSP (2).

For the comparators, we focused on RHC hemodynamics, 6-minute walk distance (6MWD), and functional class (FC) as the reference standards for assessing severity of disease. Thirty-four studies used RHC as a reference test, 15 studies used 6MWD as a reference test, and 10 studies used FC as a reference test.

Thirty-nine studies evaluated the correlation between biomarkers and/or echocardiographic parameters and the comparators. Twenty-three studies evaluated hazard ratios (HR) for death, two studies evaluated HR for a composite outcome of death or lung transplant, and one study evaluated HR for lung transplant alone. Twenty-three studies evaluated changes in mean values in response to therapy, and four studies evaluated changes in median values in response to therapy. Eight studies assessed mean or median change from baseline in response to therapy.

### Detailed Synthesis

#### Evaluation of Prognostic Value of Biomarkers and Echocardiography as Assessed by Correlation With Outcomes With Known Prognostic Ability

Table G-1 in Appendix G outlines the 39 studies that reported the correlation between a biomarker or echocardiographic parameter result and a hemodynamic or clinical outcome. The included studies consisted of a total of 1243 patients. Of studies with adults reporting age, the mean age ranged from 37 to 64 years. Two studies evaluating children reported a median age range of 7.0 to 10 years. The following were the most common comparisons encountered in the studies and included in our analysis:

- BNP versus RHC-mPAP (14 studies, 606 patients)
- BNP versus RHC-PVR (13 studies, 684 patients)
- BNP versus RHC-RAP (12 studies, 645 patients)
- BNP versus RHC-CI (10 studies, 550 patients)
- BNP versus 6MWD (9 studies, 437 patients)
- BNP versus RHC-PCWP (5 studies, 319 patients)
- Echocardiography sPAP versus RHC-sPAP (9 studies, 362 patients)

##### Meta-analysis of Correlation Studies

There appeared to be excessive heterogeneity in correlations that seemed to be explained by temporal differences between noninvasive assessment and outcome measures, whether hemodynamic at RHC or functional assessment. Therefore, we decided to limit our meta-analysis of correlation studies to those assessing correlation between baseline values at a given time. We did not include studies that correlated change in values between two tests due to the small number of these studies. To improve the robustness of the results, we also limited our meta-analysis to those comparisons that were evaluated in at least four studies. One study177 included data for both BNP and NT-proBNP and so is included twice in several analyses.

###### BNP Versus RHC-mPAP

Figure 9 shows the forest plot of the correlation between BNP and RHC-mPAP from 14 studies (606 patients) with values ranging from 0.16 to 0.62. The summary correlation coefficient was 0.39 (95% CI, 0.31 to 0.47), indicating moderate correlation between the two tests. There was moderate heterogeneity, with a Q-value of 18.8 for 14 degrees of freedom, I^2^=25.52%, p=0.17. In these studies, heterogeneity was introduced in part by different study populations. While all studies evaluated patients with PAH, there was a variety of etiologies included with some studies evaluating a specific etiology43,68,135,139,148 and others assessing a mixture of PAH etiologies.84,87,93,95,102,107,110,115,177 In addition, two studies87,177 focused on a pediatric population while the others focused on adult populations. Further, studies evaluated different BNP measurements, which may add to heterogeneity. Some studies reported results for BNP,87,93,95,110,115,135 and others reported results for NT-proBNP,43,68,84,102,107,139,148 while the Takatsuki study reported results for both.177 Some studies reported log-transformed values,68,87,93,102,135,139,148 and others reported non–log-transformed values.43,84,95,107,110,115,177 Most studies included patients receiving a variety of PAH treatments, while the Chin study focused on patients treated with epoprostenol.95 The strength of evidence is rated moderate based on most studies with low risk of bias, consistent results of an indirect outcome, and precise estimates.

Figure 9 Forest plot of correlation between BNP and RHC-mPAP

CI=confidence interval

Figure 9. Forest plot of correlation between BNP and RHC-mPAP. This figure shows the forest plot of the correlation between BNP and RHC-mPAP from 14 studies (606 patients) with values ranging from 0.16 to 0.62. The summary correlation coefficient was 0.39 (95% CI, 0.31 to 0.47), indicating moderate correlation between the two tests.

###### BNP Versus RHC-PVR

Figure 10 shows the forest plot of the correlation between BNP and RHC-PVR from 13 studies (684 patients) with values ranging from 0.06 to 081. The summary correlation coefficient was 0.46 (95% CI, 0.31 to 0.59), indicating moderate correlation between the two tests. There was high heterogeneity, with a Q-value of 71.76 for 13 degrees of freedom, I^2^=81.88%, p<0.001. In these studies, heterogeneity was also introduced by different study populations with some studies evaluating a specific etiology,43,68,135,139,144,148 and others assessing a mixture of PAH etiologies.84,87,95,102,107,115,177 In addition, two studies87,177 focused on a pediatric population while the others focused on adult populations. As with the above comparison, studies evaluated different biomarker measurements. Some studies reported results for BNP,87,95,115,135 and others reported results for NT-proBNP43,68,84,102,107,139,144,148 while one study reported outcomes for both BNP and NT-proBNP.177 Some studies reported log-transformed values,68,87,102,135,139,144,148 and others reported non–log-transformed values.43,84,95,107,115,177 Further, three studies reported PVR as an index value corrected for body size using cardiac index and PCWP,87,107,177 while the remainder reported absolute PVR value. The strength of evidence is rated low based on most studies with low risk of bias, inconsistent results of an indirect outcome, and precise estimates.

Figure 10 Forest plot of correlation between BNP and RHC-PVR

CI = confidence interval

Figure 10. Forest plot of correlation between BNP and RHC-PVR. This figure shows the forest plot of the correlation between BNP and RHC-PVR from 13 studies (684 patients) with values ranging from 0.06 to 0.81. The summary correlation coefficient was 0.46 (95% CI, 0.31 to 0.59), indicating moderate correlation between the two tests.

###### BNP Versus RHC-RAP

Figure 11 shows the forest plot of the correlation between BNP and RHC-RAP from 12 studies (645 patients) with values ranging from 0.28 to 0.68. The summary correlation coefficient was 0.47 (95% CI, 0.40 to 0.54), indicating moderate correlation between the two tests. There was moderate heterogeneity, with a Q-value of 15.5 for 12 degrees of freedom, I^2^=22.58%, p=0.22. In these studies, heterogeneity was again introduced by different study populations with a focus on specific PAH etiology in some studies68,135,144,148 and others evaluating a mixture of PAH etiologies.84,87,93,95,107,115,177,180 As with the previous comparisons, two studies87,177 focused on a pediatric population while the others focused on adult populations. Also as before, studies evaluated different biomarker measurements, with some studies reporting results for BNP,87,93,95,115,135 others reporting results for NT-proBNP,68,84,102,107,144,148 and the Takatsuki study reporting on both.177 Some studies reported log-transformed values,68,87,93,102,135,144,148 and others reported non–log-transformed values.84,95,107,115,177 The strength of evidence is rated moderate based on all but one study with low risk of bias, consistent results of an indirect outcome, and precise estimates.

Figure 11 Forest plot of correlation between BNP and RHC-RAP

CI = confidence interval

Figure 11. Forest plot of correlation between BNP and RHC-RAP. This figure shows the forest plot of the correlation between BNP and RHC-RAP from 12 studies (645 patients) with values ranging from 0.28 to 0.68. The summary correlation coefficient was 0.47 (95% CI, 0.40 to 0.54), indicating moderate correlation between the two tests.

###### BNP Versus RHC-CI

Figure 12 shows the forest plot of the correlation between BNP and RHC-CI from 10 studies (550 patients) with values ranging from −0.70 to −0.01. The summary correlation coefficient was −0.42 (95% CI, −0.54 to −0.28), indicating negative moderate correlation between the two tests. There was moderate heterogeneity, with a Q-value of 32.60 for 10 degrees of freedom, I^2^=69.33%, p<0.001. Again, heterogeneity was likely introduced by different study populations. While all studies evaluated patients with PAH, there was a variety of etiologies included, with some studies looking at a specific etiology,68,144,148 and others looking at a mixture of PAH etiologies.84,87,93,102,107,115,177 Two studies87,177 focused on a pediatric population while the others focused on adult populations. Further, studies evaluated different biomarker measurements. Some studies reported results for BNP,87,93,115 others reported results for NT-proBNP,68,84,102,107,144,148 and one reported on both BNP and NT-proBNP.177 Some studies reported log-transformed values,68,87,93,102,144,148 and others reported non–log-transformed values.84,107,115,177 The strength of evidence is rated low based on most studies with low risk of bias, inconsistent results of an indirect outcome, and precise estimates.

Figure 12 Forest plot of correlation between BNP and RHC-CI

CI=confidence interval

Figure 12. Forest plot of correlation between BNP and RHC-CI. This figure shows the forest plot of the correlation between BNP and RHC-CI from 10 studies (550 patients) with values ranging from −0.70 to −0.01. The summary correlation coefficient was −0.42 (95% CI, −0.54 to −0.28), indicating negative moderate correlation between the two tests.

###### BNP Versus 6MWD

Figure 13 shows the forest plot of the correlation between BNP and 6MWD from 9 studies (484 patients) with values ranging from −0.60 to −0.22. The summary correlation coefficient was −0.46 (95% CI, −0.55 to −0.35), indicating negative moderate correlation between the two tests. There was moderate heterogeneity, with a Q-value of 16.18 for 9 degrees of freedom, I^2^=44.37%, p=0.06. The above studies included those that focused on a certain etiology of PAH43,144,148 or a mixture of PAH etiologies.95,102,107,115,153 Two studies153,177 focused on a pediatric population while the others focused on adult populations. Studies evaluated different biomarker measurements. Some studies reported results for BNP,95,115 others reported results for NT-proBNP,43,102,107,144,148,153 while one reported on both.177 Some studies reported log-transformed values,102,144,148,153 and others reported non–log-transformed values.43,95,107,115,177 The strength of evidence is rated moderate based on most studies with low risk of bias, inconsistent results of a direct outcome, and precise estimates.

Figure 13 Forest plot of correlation between BNP and 6MWD

CI = confidence interval

Figure 13. Forest plot of correlation between BNP and 6MWD. This figure shows the forest plot of the correlation between BNP and 6MWD from 9 studies (484 patients) with values ranging from −0.60 to −0.22. The summary correlation coefficient was −0.46 (95% CI, −0.55 to −0.35), indicating negative moderate correlation between the two tests.

###### BNP Versus RHC-PCWP

Figure 14 shows the forest plot of the correlation between BNP and RHC-PCWP from 5 studies (319 patients) with values ranging from −0.03 to 0.32. The summary correlation coefficient was 0.16 (95% CI, 0.01 to 0.31), indicating poor correlation between the two tests. There was moderate heterogeneity, with a Q-value of 6.46 for 4 degrees of freedom, I^2^=38.04%, p= 0.17. Heterogeneity in this group of studies was also introduced by differing populations, with some studies looking at populations with a specific etiology of PAH,43,144 some looking at populations with a mixture of PAH etiologies,135, ^369, 595^ and the Bernus study87 focused on a pediatric population. Studies evaluated different BNP values, with some studies reporting results for BNP87,95,135 and others reporting results for NT-proBNP.43,144 Some studies reported log-transformed values87,135,144 and others reported non–log-transformed values.43,95 There is not enough information in the Rhodes study144 regarding how variables were measured to adequately explain why this study found a negative correlation between the two markers. The strength of evidence is rated low based on most studies with low risk of bias, consistent results of an indirect outcome, and imprecise estimates.

Figure 14 Forest plot of correlation between BNP and RHC-PCWP

CI=confidence interval

Figure 14. Forest plot of correlation between BNP and RHC-PCWP. This figure shows the forest plot of the correlation between BNP and RHC-PCWP from 5 studies (319 patients) with values ranging from −0.03 to 0.32. The summary correlation coefficient is 0.16 (95% CI, 0.01 to 0.31), indicating low correlation between the two tests.

###### Echocardiography sPAP Versus RHC-sPAP

Figure 15 shows the forest plot of the correlation between echocardiography sPAP and RHC-sPAP from 9 studies (362 patients) with values ranging from 0.33 to 0.97. The summary correlation coefficient was 0.76 (95% CI, 0.53 to 0.89), indicating high correlation between the two tests. There was high heterogeneity, with a Q-value of 110.59 for 8 degrees of freedom, I^2^=92.77%, p<0.001. These studies used a variety of methods to estimate sPAP by echocardiography including Bernoulli equation without correction,100,105,126 Bernoulli equation plus estimated RAP,110,113,176 and Bernoulli equation plus a fixed value for RAP;116,118 one study did not report how sPAP was estimated.112 In addition, there was variability in timing between the catheterization study and the echocardiography study. In three studies it appears that right heart catheterization and echocardiography were done during the initial evaluation.113,116,118,176 In one study, the tests were done within 30 days of each other105 and in another done within 4 to 9 months of each other.126 Two studies were retrospective chart reviews that evaluated the most recent catheterization or echocardiography results,110,112 and one prospective study did not specify a time frame between the tests.102 Most studies included patients with a wide range of disease severity, but the Homma study focused only on patients undergoing evaluation for lung transplantation.118 The strength of evidence is rated low based on most studies with low risk of bias, inconsistent results of an indirect outcome, and precise estimates.

Figure 15 Forest plot of correlation between echocardiography-sPAP and RHC-sPAP

CI = confidence interval

Figure 15. Forest plot of correlation between echocardiography-sPAP and RHC-sPAP. This figure shows the forest plot of the correlation between echocardiography-derived sPAP and RHC-sPAP from 9 studies (362 patients) with values ranging from 0.33 to 0.97. The summary correlation coefficient was 0.76 (95% CI, 0.53 to 0.89), indicating high correlation between the two tests.

#### Evaluation of Predictive Value of Biomarkers and Echocardiography as Assessed by Hazard Ratios

Table 17 summarizes the 25 studies that reported the association between a biomarker or echocardiographic parameter and a future clinical outcome in the form of a hazard ratio. Studies evaluating a hazard ratio consisted of 4624 patients, with a female-to-male ratio of 1396 to 517 in those studies reporting sex. Mean age ranged from 33 to 61 years. Included studies evaluated hazard ratios for the following outcomes:

- Mortality (17 studies reporting mean duration of 2 years, one study reporting mean duration of 9 years; 3 studies reporting median duration of 2 years) evaluating BNP (13 studies), pericardial effusion (8), RA size (5), FAC (4), RIMP/MPI/Tei index (5), TAPSE (4), uric acid (4), RV size (2), troponin T (2), peak TRV (2), mPAP (1), sPAP (1), ANP (1)
- Composite outcome of death or lung transplantation (2 studies with one reporting median duration of 4 years and the other reporting mean duration of 3 years) evaluating BNP (1 study), RA size (1), uric acid (1), peak TRV (1), pericardial effusion (1), FAC (1), RV size (1)
- Lung transplantation (one study with mean duration of 2 years) evaluating RA size
- Hospitalization (one study with mean duration of 3.7 years) evaluating BNP and uric acid

Table 17 Hazard ratio table for KQ 2

Study Population (N) Quality | Age (Variability) | Duration of Followup | Index Test | Comparator | N^a^ | Result | 95% CI | P-value
Benza, 2010^6^ Adults with PAH (N=2716) Good | Mean 50.4 (SD 16.8) | Mean followup ~18 mo | Pericardial effusion | Mortality | 2105 | 1.35 | | 0.014
Brierre, 2010^90^ Adults with PAH (N=79) Good | Median 61.4 (IQR 46.0 to 74.1) | Mean duration 12 mo | mPAP | Mortality | 79 | 3.94 | 1.34 to 11.5 | 0.012
Brierre, 2010^90^ Adults with PAH (N=79) Good | Median 61.4 (IQR 46.0 to 74.1) | Mean duration 12 mo | Pericardial effusion | Mortality | 79 | 5.18 | 1.85 to 14.5 | 0.002
Brierre, 2010^90^ Adults with PAH (N=79) Good | Median 61.4 (IQR 46.0 to 74.1) | Mean duration 12 mo | RIMP/MPI/Tei Index ≥0.98 | Mortality | 79 | 5.41 | 1.12 to 26.1 | 0.035
Brierre, 2010^90^ Adults with PAH (N=79) Good | Median 61.4 (IQR 46.0 to 74.1) | Mean duration 12 mo | TAPSE | Mortality | 79 | 0.84 | 0.72 to 0.98 | 0.024
Bustamante-Labarta, 2002^91^ Adults with PPH (N=25) Good | Mean 37.6 (SD 12.7) | Mean followup 29 mo | RA size (RA area) | Transplant (survival from) | 25 | 1.1 | | 0.0004
Fijalkowska, 2006^102^ Adults with PH (N=55) Good | Mean 41 (SD 15.1) | Mean followup 770 ± 336 days | FAC | Mortality | 55 | 0.98 | 0.93 to 1.03 | NS
Fijalkowska, 2006^102^ Adults with PH (N=55) Good | Mean 41 (SD 15.1) | Mean followup 770 ± 336 days | BNP | Mortality | 55 | 3.0 | 1.45 to 6.18 | 0.002
Fijalkowska, 2006^102^ Adults with PH (N=55) Good | Mean 41 (SD 15.1) | Mean followup 770 ± 336 days | Pericardial effusion | Mortality | 55 | 3.8 | 1.46 to 9.93 | 0.006
Fijalkowska, 2006^102^ Adults with PH (N=55) Good | Mean 41 (SD 15.1) | Mean followup 770 ± 336 days | RA size (RA area) | Mortality | 55 | 1.02 | 0.97 to 1.07 | NS
Fijalkowska, 2006^102^ Adults with PH (N=55) Good | Mean 41 (SD 15.1) | Mean followup 770 ± 336 days | RIMP/MPI/Tei index | Mortality | 55 | 1.01 | 0.34 to 3.01 | NS
Fijalkowska, 2006^102^ Adults with PH (N=55) Good | Mean 41 (SD 15.1) | Mean followup 770 ± 336 days | RV size (RV diameter) | Mortality | 55 | 1.08 | 0.99 to 1.17 | NS
Fijalkowska, 2006^102^ Adults with PH (N=55) Good | Mean 41 (SD 15.1) | Mean followup 770 ± 336 days | cTnT (detectable) | Mortality | 55 | 4.5 | 1.56 to 12.92 | 0.005
Forfia, 2006^104^ Adults with PH (N=63) Good | Mean 55 (SD 15) | Mean followup 19.3 mo | TAPSE | Mortality | 63 | 1.17 | 1.04 to 1.32 | 0.006
Ghio, 2010^108^ Adults with IPAH (N=59) Good | Mean 46.4 (SD 16.1) | Mean followup 52 mo | Pericardial effusion | Mortality | 59 | 0.79 | 0.18 to 3.4 | 0.75
Ghio, 2010^108^ Adults with IPAH (N=59) Good | Mean 46.4 (SD 16.1) | Mean followup 52 mo | RIMP/MPI/Tei Index | Mortality | 59 | 2.61 | 0.52 to 13.03 | 0.26
Ghio, 2010^108^ Adults with IPAH (N=59) Good | Mean 46.4 (SD 16.1) | Mean followup 52 mo | sPAP (transtricuspid gradient) | Mortality | 59 | 0.99 | 0.98 to 1.02 | 0.92
Ghio, 2010^108^ Adults with IPAH (N=59) Good | Mean 46.4 (SD 16.1) | Mean followup 52 mo | TAPSE | Mortality | 59 | 0.91 | 0.83 to 0.99 | 0.026
Hampole, 2009^114^ Adults with PH (N=162) Good | Mean 53 (SD 15) | Mean followup 2.1 ± 0.8 yr | BNP (log) | Mortality | 162 | 1.62 | 1.01 to 2.60 | 0.044
Heresi, 2010^115^ Adults with PPH (N=40) Good | Mean 44 (SD 14) | 23.5 ± 13.5 mo | BNP | Mortality | 40 | 1.20 | 0.11 to 13.28 | 0.88
Lorenzen, 2011^125^ Adults with PAH (N=70) Good | Mean 42 (IQR 48 to 59) | 3 mo | BNP (ln) | Mortality | 25 | 1.9 | 1.2 to 2.9 | <0.001
Lorenzen, 2011^125^ Adults with PAH (N=70) Good | Mean 42 (IQR 48 to 59) | 3 mo | Uric acid | Mortality | 25 | 1.9 | 1.5 to 2.6 | <0.001
Machado, 2006^43^ Patients with sickle cell disease (N=230) Poor | Median 33 (IQR 27 to 44) | Median followup 31 mo | BNP (log) (75^th^ percentile vs. 25^th^ percentile) | Mortality | 230 | 2.1 | 1.4 to 2.9 | <0.001
Mahapatra, 2006^127^ Adults with PH (N=54) Fair | Mean 52 (SD 11) | 250 person yr | RIMP/MPI/Tei Index | Mortality | 54 | 1.66 | 1.05 to 2.6 | 0.04
Mathai, 2011^128^ Adults with known or suspected PAH (N=50) Fair | Mean 61 (SD 11) | Median followup 15.7 mo | FAC (RVFAC) | Mortality | 50 | 0.99 | 0.95 to 1.03 | 0.47
Mathai, 2011^128^ Adults with known or suspected PAH (N=50) Fair | Mean 61 (SD 11) | Median followup 15.7 mo | Peak TRV | Mortality | 50 | 0.58 | 0.31 to 1.10 | 0.10
Mathai, 2011^128^ Adults with known or suspected PAH (N=50) Fair | Mean 61 (SD 11) | Median followup 15.7 mo | Pericardial effusion | Mortality | 50 | 1.11 | 0.75 to 1.64 | 0.59
Mathai, 2011^128^ Adults with known or suspected PAH (N=50) Fair | Mean 61 (SD 11) | Median followup 15.7 mo | RA size (RA area indexed) | Mortality | 50 | 1.11 | 1.02 to 1.19 | 0.01
Mathai, 2011^128^ Adults with known or suspected PAH (N=50) Fair | Mean 61 (SD 11) | Median followup 15.7 mo | TAPSE | Mortality | 50 | 0.87 | 0.78 to 0.96 | <0.01
Nagaya, 2000^135^ Patients with PPH (N=60) Good | Mean 38 (Range 15 to 69) | Mean followup 24 ± 2 mo | BNP | Mortality | 60 | 6.983 | 1.923 to 23.357 | 0.0031
Nagaya, 2000^135^ Patients with PPH (N=60) Good | Mean 38 (Range 15 to 69) | Mean followup 24 ± 2 mo | BNP (log) | Mortality | 53 | 29.310 | 5.294 to 162.275 | 0.0001
Nagaya, 2000^135^ Patients with PPH (N=60) Good | Mean 38 (Range 15 to 69) | Mean followup 24 ± 2 mo | ANP (log) | Mortality | 53 | 19.676 | 3.834 to 100.978 | 0.0004
Nagaya, 2000^135^ Patients with PPH (N=60) Good | Mean 38 (Range 15 to 69) | Mean followup 24 ± 2 mo | ANP | Mortality | 60 | 4.641 | 1.347 to 15.986 | 0.0150
Nickel, 2008^140^ Adults with IPAH (N=76) Fair | Mean 52 (Range 44 to 63) | Median followup 48 mo | BNP (ln) | Composite outcome (death or lung transplant) | 76 | 2.62 | 1.78 to 3.86 | <0.001
Nickel, 2008^140^ Adults with IPAH (N=76) Fair | Mean 52 (Range 44 to 63) | Median followup 48 mo | Uric acid | Composite outcome (death or lung transplant) | 76 | 1.56 | 1.27 to 1.96 | <0.001
Nickel, 2012^162^ Adults with IPAH (N=109) Fair | Median 55 (IQR 42 to 68) | Median 38 mo | BNP | Mortality | 84 | 1.3 | 1.1 to 1.6 | 0.04
Nickel, 2012^162^ Adults with IPAH (N=109) Fair | Median 55 (IQR 42 to 68) | Median 38 mo | Uric acid | Mortality | 104 | 1.1 | 1.0 to 1.6 | 0.01
Raymond, 2002^143^ Adults with PPH (N=81) Fair | Mean 40 (SD 15) | Mean followup 36.9 ± 15.4 mo | FAC | Composite outcome (death or lung transplant) | 81 | 0.86 | 0.57 to 1.28 | 0.454
Raymond, 2002^143^ Adults with PPH (N=81) Fair | Mean 40 (SD 15) | Mean followup 36.9 ± 15.4 mo | FAC | Mortality | 81 | 0.70 | 0.39 to 1.25 | 0.225
Raymond, 2002^143^ Adults with PPH (N=81) Fair | Mean 40 (SD 15) | Mean followup 36.9 ± 15.4 mo | Peak TRV | Composite outcome (death or lung transplant) | 81 | 1.00 | 0.77 to 1.30 | 0.981
Raymond, 2002^143^ Adults with PPH (N=81) Fair | Mean 40 (SD 15) | Mean followup 36.9 ± 15.4 mo | Peak TRV | Mortality | 81 | 0.90 | 0.62 to 1.31 | 0.591
Raymond, 2002^143^ Adults with PPH (N=81) Fair | Mean 40 (SD 15) | Mean followup 36.9 ± 15.4 mo | Pericardial effusion | Composite outcome (death or lung transplant) | 81 | 2.08 | 1.12 to 3.86 | 0.017
Raymond, 2002^143^ Adults with PPH (N=81) Fair | Mean 40 (SD 15) | Mean followup 36.9 ± 15.4 mo | Pericardial effusion | Mortality | 81 | 3.89 | 1.49 to 10.14 | 0.003
Raymond, 2002^143^ Adults with PPH (N=81) Fair | Mean 40 (SD 15) | Mean followup 36.9 ± 15.4 mo | RA size (RA area indexed) | Composite outcome (death or lung transplant) | 81 | 1.33 | 1.06 to 1.66 | 0.012
Raymond, 2002^143^ Adults with PPH (N=81) Fair | Mean 40 (SD 15) | Mean followup 36.9 ± 15.4 mo | RA size (RA area indexed) | Mortality | 81 | 1.54 | 1.13 to 2.10 | 0.005
Raymond, 2002^143^ Adults with PPH (N=81) Fair | Mean 40 (SD 15) | Mean followup 36.9 ± 15.4 mo | RV size (RVED area index) | Composite outcome (death or lung transplant) | 81 | 1.26 | 0.95 to 1.66 | 0.110
Raymond, 2002^143^ Adults with PPH (N=81) Fair | Mean 40 (SD 15) | Mean followup 36.9 ± 15.4 mo | RV size (RVED area index) | Mortality | 81 | 1.34 | 0.90 to 1.98 | 0.148
Rhodes, 2011^144^ Adults with IPAH (N=139) Good | Mean 47.6 (SD 15.8) | 2 yr | BNP (square root) | Mortality | 139 | 1.038 | 1.018 to 1.058 | <0.001
Sadushi-Kolici, 2012^160^ Adults with PH (N=111) Fair | Mean 52 (SD 17) | 9 yrs | Pericardial effusion | Mortality | 105 | 6.361 | | 0.003
Takeda, 2010^149^ Adults with PAH (N=37) Good | Mean 49 (SD 18) | 635 ± 510 days | BNP (log) | Mortality | 37 | 2.79 | 1.55 to 5.04 | 0.001
Torbicki, 2003^150^ Adults with PAH (N=56) Good | Mean 41 (SD 15) | Mean followup 17 ± 8.5 mo | FAC | Mortality | 56 | 0.999 | 0.94 to 1.06 | 0.96
Torbicki, 2003^150^ Adults with PAH (N=56) Good | Mean 41 (SD 15) | Mean followup 17 ± 8.5 mo | BNP >median (1647 pg/mL) | Mortality | 56 | 1.84 | 0.89 to 5.45 | 0.32
Torbicki, 2003^150^ Adults with PAH (N=56) Good | Mean 41 (SD 15) | Mean followup 17 ± 8.5 mo | Pericardial effusion | Mortality | 56 | 2.77 | 0.89 to 8.59 | 0.08
Torbicki, 2003^150^ Adults with PAH (N=56) Good | Mean 41 (SD 15) | Mean followup 17 ± 8.5 mo | RA size (RA area) | Mortality | 56 | 1.03 | 0.97 to 1.09 | 0.39
Torbicki, 2003^150^ Adults with PAH (N=56) Good | Mean 41 (SD 15) | Mean followup 17 ± 8.5 mo | cTnT (detectable) | Mortality | 56 | 5.47 | 1.62 to 18.46 | 0.003
Utsunomiya, 2011^151^ Adults with chronic PH (N=50) Good | Mean 46 (SD 13) | | BNP | Mortality | 50 | | | 0.006
Utsunomiya, 2011^151^ Adults with chronic PH (N=50) Good | Mean 46 (SD 13) | | RA size (RA end systolic area indexed) | Mortality | 50 | | | 0.005
Utsunomiya, 2011^151^ Adults with chronic PH (N=50) Good | Mean 46 (SD 13) | | RIMP/MPI/Tei index | Mortality | 50 | | | 0.005
Williams, 2006^68^ Adults with systemic sclerosis (N=109) Fair | Mean 60 (SD 10) | 1 yr | BNP (10-fold increase FROM baseline) | Mortality | 68 | 3.82 | 1.46 to 9.96 | 0.006
Williams, 2006^68^ Adults with systemic sclerosis (N=109) Fair | Mean 60 (SD 10) | 1 yr | BNP (10-fold increase IN baseline) | Mortality | 68 | 4.82 | 1.29 to 18.05 | 0.002
Yamada, 2012^161^ Patients with IPAH (N=41) Good | Mean 39 (SD 14) | 45 ± 25 mo | BNP | Mortality | 41 | 1.00 | 1.00 to 1.00 | 0.197
Yamada, 2012^161^ Patients with IPAH (N=41) Good | Mean 39 (SD 14) | 45 ± 25 mo | Uric acid | Mortality | 41 | 1.38 | 0.95 to 2.00 | 0.087
Yamada, 2012^161^ Patients with IPAH (N=41) Good | Mean 39 (SD 14) | 45 ± 25 mo | BNP | Hospitalization | 41 | 1.00 | 1.00 to 1.00 | 0.129
Yamada, 2012^161^ Patients with IPAH (N=41) Good | Mean 39 (SD 14) | 45 ± 25 mo | Uric acid | Hospitalization | 41 | 1.25 | 0.98 to 1.59 | 0.075
Yanagisawa, 2012^159^ Adults with PAH (N=46) Good | Mean 42 (SD 14) | 44 ± 26 mo | BNP | Mortality | 46 | 1.00 | 0.99 to 1.00 | NS
Zhao, 2012^163^ Patients with IPAH (N=76) Good | Mean 37 (SD 11) | Mean 24 ± 9 mo | Uric acid | Mortality | 76 | 1.003 | 1.000 to 1.006 | 0.049

ANP = A-type natriuretic peptide; BNP = B-type natriuretic peptide; CO = cardiac output; cTnT = cardiac troponin T; CVD = collagen vascular disease; FAC = fractional area change; IQR = interquartile range; mPAP = mean pulmonary artery pressure; mo = month/months; MPI = myocardial performance index; NR = not reported; PVR = pulmonary vascular resistance; RA = right atrium; RIMP = right index of myocardial performance; RV = right ventricle; SD = standard deviation; SEM = standard error of the mean; sPAP = systolic pulmonary artery pressure; TAPSE = tricuspid annular plane systolic excursion; TRV = tricuspid regurgitant jet velocity; yr = year/years

a Number of patients who had the index test and comparator measured.

##### Meta-Analysis of Hazard Ratio Studies

There were too few studies to permit meta-analysis assessing hazard ratios for a composite outcome. Our analysis focused on those studies that evaluated biomarkers or echocardiographic parameters as predictors of mortality. To improve the robustness of the analysis, we included only index tests that were evaluated in at least four different studies. We also concentrated on univariate hazard ratios as each study that created a multivariate model adjusted for different variables. We did not include those studies that evaluated a biomarker or echocardiographic parameter as a dichotomous outcome since these studies tended use markedly different thresholds across studies.

###### BNP and Mortality

Figures 16 and 17 show forest plots of the hazard ratios for BNP and mortality from 11 studies (757 patients), with values ranging from 1.62 to 6.98. Studies differed in whether and how BNP values, which tend to have a skewed distribution, were transformed for use in their analyses. Most studies used log-transformation of BNP values, while others did not describe any transformation or used a different transformation method (e.g., square root in one study). We segregated our analysis according to whether BNP values were log-transformed and found that this explained a great deal of the statistical heterogeneity of results—reducing the initial Q-value of 73.2 for 10 degrees of freedom, I^2^=86.34, to Q-value of 7.78 for 5 degrees of freedom, I^2^=35.72%, p=0.17, among studies using log-transformed BNP values, and Q-value of 26.10 for 4 degrees of freedom, I^2^=84.68%, p<0.001, for studies using no transformation method or a different transformation method.

Figure 16 Forest plot of hazard ratio for log-transformed BNP and mortality

CI = confidence interval

Figure 16. Forest plot of hazard ratio for log-transformed BNP and mortality. This figure shows the forest plot of the hazard ratio for log-transformed BNP and mortality from 6 studies with values ranging from 1.62 to 6.98. For those studies that analyzed log-transformed values for BNP, the summary hazard ratio was 2.42 (95% CI, 1.72 to 3.41), indicating that higher levels of BNP are associated with higher mortality.

Figure 17 Forest plot of hazard ratio for BNP (without mention of log-transformation) and mortality

CI = confidence interval

Figure 17. Forest plot of hazard ratio for BNP (without mention of log-transformation) and mortality. This figure shows a forest plot of the hazard ration for BNP and mortality from 5 studies in which BNP values were not log-transformed with values ranging from 1.00 to 1.30. The summary hazard ratio was 1.01 (95% CI, 0.99 to 1.03), suggesting no association with mortality; however, we believe that these analyses suffer from limited statistical power to detect any effect and perhaps obscure any observed effect through rounding error (e.g., one study reported a hazard ratio of 1 with 95% CI from 1.0 to 1.0).

Given the reduction in heterogeneity, we analyzed those studies reporting a log-transformed value for BNP separately from the other studies. For those studies that analyzed log-transformed values for BNP, the summary hazard ratio was 2.42 (95% CI, 1.72 to 3.41), indicating that higher levels of BNP are associated with higher mortality (Figure 16). Studies differed in study population, with some looking at populations with a specific etiology for PAH68,125 and others looking at mixed populations.102,114,135,149 Studies evaluated either BNP135,149 or NT-proBNP.68,102,114,125 For those studies in which BNP values were not log-transformed, the summary hazard ratio was 1.01 (95% CI, 0.99 to 1.03), suggesting no association with mortality (Figure 17); however, we believe that these analyses suffer from limited statistical power to detect any effect and perhaps obscure any observed effect through rounding error (e.g., one study reported a hazard ratio of 1 with 95% CI from 1.0 to 1.0). Studies differed in study population, with some evaluating populations with a specific etiology for PAH144,161,162 and others evaluating mixed populations.115,159 Studies evaluated either BNP115,159,161 or NT-proBNP.144,162 We based our assessment primarily on the studies that used log-transformed BNP values. Overall for BNP, the strength of evidence is moderate based on most studies with low risk of bias, consistent results of a direct outcome, and imprecise estimates.

###### Pericardial Effusion and Mortality

Figure 18 shows the forest plot of the hazard ratio for presence of pericardial effusion and mortality from 8 studies (2590 patients) with values ranging from 0.79 to 6.36. The summary hazard ratio was 2.43 (95% CI, 1.57 to 3.77), indicating that the presence of pericardial effusion is associated with higher mortality. There was moderate heterogeneity, with a Q-value of 20.79 for 7 degrees of freedom, I^2^=66.32%, p<0.001. The two studies that reported an effect estimate smaller than the summary estimate108,128 reported the pericardial effusion value as a combined value incorporating both presence and grade or severity. The other six studies reported only presence of effusion. The strength of evidence is rated moderate based on five studies with low risk of bias and three with moderate risk of bias, inconsistent results of a direct outcome, and imprecise estimates.

Figure 18 Forest plot of hazard ratio for pericardial effusion and mortality

CI = confidence interval

Figure 18. Forest plot of hazard ratio for pericardial effusion and mortality. This figure shows the forest plot of the hazard ratio for pericardial effusion and mortality from 8 studies (2590 patients) with values ranging from 0.79 to 6.36. The summary hazard ratio was 2.43 (95% CI, 1.57 to 3.77), indicating that the presence of pericardial effusion is associated with higher mortality.

###### RA Size and Mortality

Figure 19 shows the forest plot of the hazard ratio for RA size and mortality from 4 studies (242 patients) with values ranging from 1.02 to 1.11 per 1 cm^2^ increment in RA size or per 1 cm^2^/m increment in RA index. The summary hazard ratio was 1.06 (95% CI, 1.01 to 1.10), indicating that increased RA size is associated with increased mortality. There was moderate heterogeneity, with a Q-value of 5.04 for 3 degrees of freedom, I^2^=40.51%, p=0.17. Some of the heterogeneity may be explained by the fact that both the Raymond study143 and the Mathai study128 reported RA area indexed to patient height while the others did not. We could find no other significant differences in the studies to explain the heterogeneity. The strength of evidence is rated moderate based on two studies with low risk of bias and two with moderate risk of bias, consistent results of a direct outcome, and precise estimates.

Figure 19 Forest plot of hazard ratio for RA size and mortality

CI = confidence interval

Figure 19. Forest plot of hazard ratio for RA size and mortality. This figure shows the forest plot of the hazard ratio for RA size and mortality from 4 studies (242 patients) with values ranging from 1.02 to 1.11. The summary hazard ratio was 1.06 (95% CI, 1.01 to 1.10), indicating that increased RA size is associated with increased mortality.

###### FAC and Mortality

Figure 20 shows the forest plot of the hazard ratio for FAC and mortality from 4 studies (242 patients) with values ranging from 0.96 to 1.0 per 0.01 (1%) increment in FAC. The summary hazard ratio was 0.98 (95% CI, 0.96 to 1.01), indicating that differences in FAC had no relationship to mortality. There was low heterogeneity, with a Q-value of 0.79 for 3 degrees of freedom, I^2^=0, p= 0.85. The strength of evidence is rated moderate based on two studies with low risk of bias and two with moderate risk of bias, consistent results of a direct outcome, and precise estimates.

Figure 20 Forest plot of hazard ratio for FAC and mortality

CI = confidence interval

Figure 20. Forest plot of hazard ratio for FAC and mortality. This figure shows the forest plot of the hazard ratio for FAC and mortality from 4 studies (242 patients) with values ranging from 0.96 to 1.0 per 0.01 (1%) increment in FAC. The summary hazard ratio was 0.98 (95% CI, 0.96 to 1.01), indicating that differences in FAC had no relationship to mortality.

###### Uric Acid and Mortality

Figure 21 shows the forest plot of the hazard ratio for uric acid and mortality from 4 studies (246 patients) with values ranging from 1.00 to 1.10 per 1 μmol/L increment in serum uric acid level. The summary hazard ratio was 1.01 (95% CI, 1.00 to 1.01), suggesting that differences in serum uric acid level had a small but detectable effect on risk of mortality. There was moderate heterogeneity, with a Q-value of 11.65 for 3 degrees of freedom, I^2^=74.25%, p=0.01. Heterogeneity in these studies may have been introduced by different scales of measurements across studies and different populations. Lorenzen et al.125 reported a statistically significant hazard ratio of 1.9 (CI, 1.5 to 2.6) for a 100 μmol/L increment in serum uric acid level; however, other studies reported hazard ratios calculated for 1 μmol/L or 1 mg/dL increments, and rounding error in the estimates precluded adjustment to a larger (clinically important) increment. Three studies161–163 evaluated patients with IPAH, while the Lorenzen study evaluated patients with PAH from multiple etiologies.125 The strength of evidence is rated low based on three studies with low risk of bias and one with moderate risk of bias, inconsistent results of a direct outcome, and imprecise estimates.

Figure 21 Forest plot of hazard ratio for serum uric acid level and mortality

CI = confidence interval

Figure 21. Forest plot of hazard ratio for serum uric acid level and mortality. This figure shows the forest plot of the hazard ratio for uric acid and mortality from 4 studies (246 patients) with values ranging from 1.00 to 1.10 per 1 μmol/L increment in serum uric acid level. The summary hazard ratio was 1.01 (95% CI, 1.00 to 1.01), indicating that differences in serum uric acid level had no detectable effect on risk of mortality.

###### TAPSE and Mortality

Figure 22 shows the forest plot of the hazard ratio for TAPSE and mortality from 4 studies (251 patients) with values ranging from 0.84 to 1.17. The summary hazard ratio was 0.94 (95% CI, 0.82 to 1.08), indicating that differences in TAPSE had no significant relationship to mortality. There was moderate heterogeneity, with a Q-value of 17.9 for 3 degrees of freedom, I^2^=83.24%, p<0.001. Heterogeneity in these studies may have been introduced by different scales of measurements across studies and different populations. The strength of evidence is rated insufficient based on three studies with low risk of bias and one with moderate risk of bias, inconsistent results of a direct outcome, and precise estimates.

Figure 22 Forest plot of hazard ratio for TAPSE and mortality

CI = confidence interval

Figure 22. Forest plot of hazard ratio for TAPSE and mortality. This figure shows the forest plot of the hazard ratio for TAPSE and mortality from 4 studies (251 patients) with values ranging from 0.84 to 1.17. The summary hazard ratio was 0.94 (95% CI, 0.82 to 1.08), indicating that differences in TAPSE had no significant relationship to mortality.

#### Evaluation of Responsiveness of Biomarkers and Echocardiography as Assessed by Changes in Mean or Median Levels

In our review, we focused only on those studies that measured mean or median values for biomarkers or echocardiographic parameters at two or more different time points or reported as a change from baseline, in order to evaluate whether changes in these measures could serve as a potential surrogate marker for response to therapy. Tables 17–19 show means, medians, and changes in either mean or median from baseline.

- Twenty-three studies including 1051 patients evaluated changes in mean values in response to therapy for a subset of 913 patients evaluating BNP (13 studies), sPAP (5), RV size (5), RIMP/MPI/Tei index (3), TRV (3), TAPSE (1), FAC (1), mPAP (1), nitric oxide (1), endothelin-1 (1) and RA size (1).
- Four studies with a total of 37 patients evaluated changes in median in response to therapy evaluating BNP (4 studies), Endothelin-1 (1), RIMP/MPI/Tei index (1), sPAP (1), FAC (1), RVEF (1).
- Eight studies with a total 935 patients evaluated mean or median change from baseline in response to therapy for a subset of 610 patients evaluating BNP (5 studies), mPAP (3), RV size (2), FAC (1), TRV (1), RIMP/MPI/Tei index (1), RA size (1) and cardiac index (1).
- Response to therapy was evaluated for the following drugs: ambrisentan (6 studies), bosentan (11), epoprostenol (10), iloprost (2), sildenafil (1), tadalafil (2), and treprostinil (3).

Table 18 Studies reporting changes in mean values over time

Study Population (N) Quality | Age (Variability) | Timing | Index Test | N | Mean | Variability | Clinical Scenario
Bharani, 2007^88^ Adults and children with suspected or symptomatic PAH (N=8) Fair | Mean 28 (SD 9.38) | Baseline | sPAP | 8 | 114.12 | SD 23.14 | Response to tadalafil
Bharani, 2007^88^ Adults and children with suspected or symptomatic PAH (N=8) Fair | Mean 28 (SD 9.38) | 1 mo | sPAP | 8 | 88.75 | SD 23.26 | Response to tadalafil
Campana, 2004^93^ Adults with precapillary PH (N=22) Good | Mean 50 (SD 11) | Baseline | FAC | 22 | 0.26 | SD 0.10 | Response to epoprostenol
Campana, 2004^93^ Adults with precapillary PH (N=22) Good | Mean 50 (SD 11) | Mean followup 15 ± 4 mo | FAC | 22 | 0.23 | SD 0.08 p=0.8 | Response to epoprostenol
Campana, 2004^93^ Adults with precapillary PH (N=22) Good | Mean 50 (SD 11) | Baseline | BNP | 22 | 246 | SD 162 | Response to epoprostenol
Campana, 2004^93^ Adults with precapillary PH (N=22) Good | Mean 50 (SD 11) | Mean followup 15 ± 4 mo | BNP | 22 | 256 | SD 180 p=0.9 | Response to epoprostenol
Campana, 2004^93^ Adults with precapillary PH (N=22) Good | Mean 50 (SD 11) | Baseline | RV size (RV end diastolic diameter) | 22 | 36 | SD 7.5 | Response to epoprostenol
Campana, 2004^93^ Adults with precapillary PH (N=22) Good | Mean 50 (SD 11) | Mean followup 15 ± 4 mo | RV size (RV end diastolic diameter) | 22 | 39 | SD 7.3 p=0.09 | Response to epoprostenol
Campana, 2004^93^ Adults with precapillary PH (N=22) Good | Mean 50 (SD 11) | Baseline | TAPSE | 22 | 17.3 | SD 4.4 | Response to epoprostenol
Campana, 2004^93^ Adults with precapillary PH (N=22) Good | Mean 50 (SD 11) | Mean followup 15 ± 4 mo | TAPSE | 22 | 15.2 | SD 4.4 p=0.04 | Response to epoprostenol
Cella, 2009^92^ Adults with PAH associated with CTD (N=18) Good | Mean 53.8 (SD 13.1) | Baseline | Nitric oxide | 18 | 24.05 | SD 6.04 | Response to bosentan
Cella, 2009^92^ Adults with PAH associated with CTD (N=18) Good | Mean 53.8 (SD 13.1) | 1 yr | Nitric oxide | 18 | 13.92 | SD 3.40 p<0.001 | Response to bosentan
D’Alto, 2010^96^ Adults with PAH due to CHD (N=32) Fair | Mean 37.1 (SD 13.7) | Baseline | BNP | 32 | 760 | SD 943 | Response to bosentan + sildenafil
D’Alto, 2010^96^ Adults with PAH due to CHD (N=32) Fair | Mean 37.1 (SD 13.7) | 6 mo | BNP | 32 | 303 | SD 366 p=0.008 | Response to bosentan + sildenafil
Feliciano, 2004^101^ Adults with severe PAH (N=11) Good | Mean 42 (SD 18) | Baseline | RIMP/MPI/Tei index | 11 | 0.8 | SD 0.6 | Bosentan or iloprost
Feliciano, 2004^101^ Adults with severe PAH (N=11) Good | Mean 42 (SD 18) | 11.3 ± 7.9 mo | RIMP/MPI/Tei index | 11 | 0.7 | SD 0.4 p=0.02 (compared with baseline) | Bosentan or iloprost
Galie, 2008^106^ Adults with PAH (N=201) Good | NR | Baseline | BNP | 394 | 122.92 | 95% CI 93.30 to 160.82 | Response to ambrisentan 5mg (Aries I)
Galie, 2008^106^ Adults with PAH (N=201) Good | NR | 12 wk | BNP | 394 | 85.75 | 95% CI 66.01 to 111.23 | Response to ambrisentan 5mg (Aries I)
Galie, 2008^106^ Adults with PAH (N=201) Good | NR | Baseline | BNP | 394 | 132.07 | 95% CI 89.72 to 193.86 | Response to ambrisentan10mg (Aries I)
Galie, 2008^106^ Adults with PAH (N=201) Good | NR | 12 wk | BNP | 394 | 72.29 | 95% CI 53.50 to 98.72 | Response to ambrisentan10mg (Aries I)
Galie, 2008^106^ Adults with PAH (N=201) Good | NR | Baseline | BNP | 394 | 129.94 | 95% CI 89.49 to 188.22 | Response to ambrisentan 2.5mg (Aries II)
Galie, 2008^106^ Adults with PAH (N=201) Good | NR | 12 wk | BNP | 394 | 92.68 | 95% CI 69.43 to 124.84 | Response to ambrisentan 2.5mg (Aries II)
Galie, 2008^106^ Adults with PAH (N=201) Good | NR | Baseline | BNP | 394 | 89.81 | 95% CI 58.92 to 137.58 | Response to ambrisentan 5mg (Aries II)
Galie, 2008^106^ Adults with PAH (N=201) Good | NR | 12 wk | BNP | 394 | 62.74 | 95% CI 42.36 to 93.63 | Response to ambrisentan 5mg (Aries II)
Jacobs, 2009^119^ Adults with idiopathic PAH (N=16) Fair | Mean 37.0 (SD 2.8) | Baseline | BNP | 11 | 2830 | SEM 818 | Response to prostanoids
Jacobs, 2009^119^ Adults with idiopathic PAH (N=16) Fair | Mean 37.0 (SD 2.8) | Mean followup 37.0 ± 4.4 mo | BNP | 11 | 1574 | SEM 447 p=0.049 | Response to prostanoids
Kaya, 2012^165^ Patients with Eisenmenger syndrome (N=23) Good | Mean 31 (SD 12) | Baseline | RV size | 23 | 35.3 | SD 10.5 | Response to bosentan
Kaya, 2012^165^ Patients with Eisenmenger syndrome (N=23) Good | Mean 31 (SD 12) | Mean followup 24 ± 9 mo | RV size | 23 | 31.8 | SD 10.3 p=0.066 | Response to bosentan
Kaya, 2012^165^ Patients with Eisenmenger syndrome (N=23) Good | Mean 31 (SD 12) | Baseline | RA size | 23 | 40.5 | SD 4.5 | Response to bosentan
Kaya, 2012^165^ Patients with Eisenmenger syndrome (N=23) Good | Mean 31 (SD 12) | Mean followup 24 ± 9 mo | RA size | 23 | 35.4 | 5.2 p=0.14 | Response to bosentan
Kaya, 2012^165^ Patients with Eisenmenger syndrome (N=23) Good | Mean 31 (SD 12) | Baseline | sPAP | 23 | 118 | SD 22 | Response to bosentan
Kaya, 2012^165^ Patients with Eisenmenger syndrome (N=23) Good | Mean 31 (SD 12) | Mean followup 24 ± 9 mo | sPAP | 23 | 111 | SD 19 p=0.044 | Response to bosentan
Kaya, 2012^165^ Patients with Eisenmenger syndrome (N=23) Good | Mean 31 (SD 12) | Baseline | s-prime | 23 | 6.7 | SD 1.5 | Response to bosentan
Kaya, 2012^165^ Patients with Eisenmenger syndrome (N=23) Good | Mean 31 (SD 12) | Mean followup 24 ± 9 mo | s-prime | 23 | 8.8 | SD 1.7 p=0.003 | Response to bosentan
Keogh, 2011^121^ Adults with PAH (N=112) Fair | Mean 51.4 (SD 17.8) | Baseline (at start of monotherapy) | sPAP | 101 | 83 | SD 23 | Response to monotherapy
Keogh, 2011^121^ Adults with PAH (N=112) Fair | Mean 51.4 (SD 17.8) | Mean followup 18.7 ± 13.4 mo on monotherapy | sPAP | 103 | 86 | SD 25 | Response to monotherapy
Keogh, 2011^121^ Adults with PAH (N=112) Fair | Mean 51.4 (SD 17.8) | 1 yr after starting combination therapy | sPAP | 112 | 77 | SD 22 | Response to combo therapy
Knirsch, 2011^129^ Children with heart disease (N=103) Good | Mean 6.4 (SD 5.2) | Baseline | BNP | 4 | 980.5 | SD 994.9 | Before treatment in patients with IPAH
Knirsch, 2011^129^ Children with heart disease (N=103) Good | Mean 6.4 (SD 5.2) | Baseline | BNP | 6 | 665.2 | SD 1371 | Before treatment in patients with PAH 2/2 CHD
Knirsch, 2011^129^ Children with heart disease (N=103) Good | Mean 6.4 (SD 5.2) | No followup time specified | BNP | 8 | 25.6 | SD 13.2 p<0.05 | Response to standardized protocol in patients with IPAH
Knirsch, 2011^129^ Children with heart disease (N=103) Good | Mean 6.4 (SD 5.2) | No followup time specified | BNP | 15 | 152.9 | SD 224.4 p<0.05 | Response to standardized protocol in patients with PAH 2/2 CHD
Langleben, 1999^123^ Patients with PPH (N=18) Good | NR | Baseline | Endothelin-1 | 11 | 1.62 | SEM 0.35 | Response to epoprostenol
Langleben, 1999^123^ Patients with PPH (N=18) Good | NR | 3 mo | Endothelin-1 | 11 | 1.84 | SEM 0.41 | Response to epoprostenol
Leuchte, 2005^124^ Adults with PAH (N=30) Good | Mean 46.93 (SEM 2.8) | Baseline | BNP | 30 | 45.51 | SEM 7.52 | Comparison to therapy (nonspecific)
Leuchte, 2005^124^ Adults with PAH (N=30) Good | Mean 46.93 (SEM 2.8) | Mean followup 12.6 ± 1.5 mo | BNP | 30 | 58.2 | SEM 11.4 | Comparison to therapy (nonspecific)
Minniti, 2009^133^ Adults with SCD and PH (N=14) Poor | Mean 48.9 | Baseline | BNP | 14 | 407 | SD 172 | Response to bosentan or ambrisentan
Minniti, 2009^133^ Adults with SCD and PH (N=14) Poor | Mean 48.9 | 2 mo | BNP | 14 | 286 | SD 63 | Response to bosentan or ambrisentan
Minniti, 2009^133^ Adults with SCD and PH (N=14) Poor | Mean 48.9 | 3 mo | BNP | 14 | 224 | SD 46 | Response to bosentan or ambrisentan
Minniti, 2009^133^ Adults with SCD and PH (N=14) Poor | Mean 48.9 | Baseline | TRV | 14 | 3.4 | SD 0.1 | Response to bosentan or ambrisentan
Minniti, 2009^133^ Adults with SCD and PH (N=14) Poor | Mean 48.9 | 2 mo | TRV | 14 | 3.4 | SD 0.1 | Response to bosentan or ambrisentan
Minniti, 2009^133^ Adults with SCD and PH (N=14) Poor | Mean 48.9 | 3 mo | TRV | 14 | 3.3 | SD 0.1 | Response to bosentan or ambrisentan
Minniti, 2009^133^ Adults with SCD and PH (N=14) Poor | Mean 48.9 | 6 mo | TRV | 14 | 3.3 | SD 0.2 | Response to bosentan or ambrisentan
Morishita, 2009^138^ Adults and children with PAH (N=7) Good | Median 34.6 (Range 15 to 49) | 1 mo | RA size (RA area indexed) | 7 | 18.6 | SD 10.4 | Response to epoprostenol
Morishita, 2009^138^ Adults and children with PAH (N=7) Good | Median 34.6 (Range 15 to 49) | 3 mo | RA size (RA area indexed) | 7 | 19.4 | SD 10.7 | Response to epoprostenol
Morishita, 2009^138^ Adults and children with PAH (N=7) Good | Median 34.6 (Range 15 to 49) | 6 mo | RA size (RA area indexed) | 7 | 14.6 | SD 5.4 | Response to epoprostenol
Morishita, 2009^138^ Adults and children with PAH (N=7) Good | Median 34.6 (Range 15 to 49) | 1 yr | RA size (RA area indexed) | 7 | 14.5 | SD 5.8 | Response to epoprostenol
Nakayama, 2007^136^ Patients with PPH (N=60) Good | Mean 10.7 (SD 3.5) | 3 mo | BNP | 27 | 187.0 | SD 221.4 | Response to epoprostenol
Nakayama, 2007^136^ Patients with PPH (N=60) Good | Mean 10.7 (SD 3.5) | 1 yr | BNP | 27 | 86.6 | SD 133.9 | Response to epoprostenol
Nakayama, 2007^136^ Patients with PPH (N=60) Good | Mean 10.7 (SD 3.5) | 2 yr | BNP | 27 | 85.3 | SD 206.1 | Response to epoprostenol
Nath, 2005^137^ Adults with PPH (N=20) Good | Mean 46 (SD 11) | Baseline | RIMP/MPI/Tei index | 20 | 0.6 | SD 0.3 | Response to epoprostenol
Nath, 2005^137^ Adults with PPH (N=20) Good | Mean 46 (SD 11) | 22.7 ± 9.3 mo | RIMP/MPI/Tei index | 20 | 0.6 | SD 0.3 p=0.54 | Response to epoprostenol
Nath, 2005^137^ Adults with PPH (N=20) Good | Mean 46 (SD 11) | Baseline | RV size | 20 | 2.1 | SD 0.9 | Response to epoprostenol
Nath, 2005^137^ Adults with PPH (N=20) Good | Mean 46 (SD 11) | 22.7 ± 9.3 mo | RV size | 20 | 1.8 | SD 1.5 p=0.07 | Response to epoprostenol
Nath, 2005^137^ Adults with PPH (N=20) Good | Mean 46 (SD 11) | Baseline | sPAP | 20 | 87 | SD 26 | Response to epoprostenol
Nath, 2005^137^ Adults with PPH (N=20) Good | Mean 46 (SD 11) | 22.7 ± 9.3 mo | sPAP | 20 | 75 | SD 24 p=0.02 | Response to epoprostenol
Nath, 2005^137^ Adults with PPH (N=20) Good | Mean 46 (SD 11) | Baseline | TRV | 20 | 4.2 | SD 0.6 | Response to epoprostenol
Nath, 2005^137^ Adults with PPH (N=20) Good | Mean 46 (SD 11) | 22.7 ± 9.3 mo | TRV | 20 | 3.8 | SD 0.7 p=0.02 | Response to epoprostenol
Ogawa, 2012^167^ Patients with pulmonary veno-occlusive disease or pulmonary capillary hemangiomatosis (N=8) Fair | Mean 26.0 (SD 3.1) | Baseline | BNP | 8 | 381.3 | SD 136.8 | Response to epoprostenol
Ogawa, 2012^167^ Patients with pulmonary veno-occlusive disease or pulmonary capillary hemangiomatosis (N=8) Fair | Mean 26.0 (SD 3.1) | 12 mo | BNP | 8 | 55.2 | 14.4 p=0.05 | Response to epoprostenol
Sebbag, 2001^146^ Adults and children with PPH (N=16) Good | Mean 43 (SD 16) | Baseline | RIMP/MPI/Tei index | 16 | 0.72 | SD 0.22 | Response to epoprostenol
Sebbag, 2001^146^ Adults and children with PPH (N=16) Good | Mean 43 (SD 16) | 5.9 ± 4.6 mo | RIMP/MPI/Tei index | 16 | 0.64 | SD 0.17 p=0.05 | Response to epoprostenol
Sebbag, 2001^146^ Adults and children with PPH (N=16) Good | Mean 43 (SD 16) | Baseline | sPAP | 16 | 108 | SD 19 | Response to epoprostenol
Sebbag, 2001^146^ Adults and children with PPH (N=16) Good | Mean 43 (SD 16) | 5.9 ± 4.6 mo | sPAP | 16 | 94 | SD 22 p=0.03 | Response to epoprostenol
Simeoni, 2008^58^ Adults with systemic sclerosis and PH (N=20) Good | Median 55 (Range 40 to 70) | Baseline | BNP | 10 | 23.4 pmol/L | Range 11.1 to 38 | Response to bosentan
Simeoni, 2008^58^ Adults with systemic sclerosis and PH (N=20) Good | Median 55 (Range 40 to 70) | 3 mo | BNP | 10 | 26 | Range 4.54 to 144 p=0.953 | Response to bosentan
Simeoni, 2008^58^ Adults with systemic sclerosis and PH (N=20) Good | Median 55 (Range 40 to 70) | 7 mo | BNP | 10 | 15.7 | Range 6 to 79 p=0.600 | Response to bosentan
Taguchi, 2012^168^ Patients with IPAH (N=65) Good | Mean 40 (SD 13) | Baseline | BNP | 65 | 248 | SD 327 | Response to combination therapy
Taguchi, 2012^168^ Patients with IPAH (N=65) Good | Mean 40 (SD 13) | Mean followup 37 ± 17 mo | BNP | 65 | 46 | SD 59 p=0.085 | Response to combination therapy
Takatsuki, 2012^172^ Children with PAH (N=33) Good | Median 10 (Range 4 to 18) | Baseline | TRJ velocity | 21 | 4.1 | SD 0.7 | Response to tadalafil
Takatsuki, 2012^172^ Children with PAH (N=33) Good | Median 10 (Range 4 to 18) | 9.0 ± 7.2 mo | TRJ velocity | 21 | 3.9 | SD 0.8 p=NS | Response to tadalafil
Takatsuki, 2012^172^ Children with PAH (N=33) Good | Median 10 (Range 4 to 18) | Baseline | RV size | 19 | 24.5 | SD 10.1 | Response to tadalafil
Takatsuki, 2012^172^ Children with PAH (N=33) Good | Median 10 (Range 4 to 18) | 9.0 ± 7.2 mo | RV size | 19 | 23.6 | SD 8.8 p=NS | Response to tadalafil
Takatsuki, 2012^172^ Children with PAH (N=33) Good | Median 10 (Range 4 to 18) | Baseline | BNP | 24 | 102.2 | SD 283.3 | Response to tadalafil
Takatsuki, 2012^172^ Children with PAH (N=33) Good | Median 10 (Range 4 to 18) | 9.0 ± 7.2 mo | BNP | 24 | 100.2 | SD 160 p=NS | Response to tadalafil
Takatsuki, 2012^173^ Children with PAH (N=38) Good | Median 11 (Range 2–18) | Baseline | BNP | 15 | 49 | SD 34 | Response to transition to ambrisentan
Takatsuki, 2012^173^ Children with PAH (N=38) Good | Median 11 (Range 2–18) | Median followup 20 mo | BNP | 15 | 72 | SD 47 p=NS | Response to transition to ambrisentan
Takatsuki, 2012^173^ Children with PAH (N=38) Good | Median 11 (Range 2–18) | Baseline | BNP | 23 | 81 | SD 105 | Response to the addition of ambrisentan
Takatsuki, 2012^173^ Children with PAH (N=38) Good | Median 11 (Range 2–18) | Median followup 20 mo | BNP | 23 | 53 | SD 41 p=NS | Response to the addition of ambrisentan
Yang, 2012^169^ Patients with Eisenmenger syndrome (N=12) Fair | Mean 33.2 (SD 12.1) | Baseline | RV size | 12 | 53.7 | SD 4.8 | Response to iloprost
Yang, 2012^169^ Patients with Eisenmenger syndrome (N=12) Fair | Mean 33.2 (SD 12.1) | Mean followup 18.6 ± 7.4 mo | RV size | 12 | 51.4 | SD 3.9 p=0.068 | Response to iloprost
Yang, 2012^169^ Patients with Eisenmenger syndrome (N=12) Fair | Mean 33.2 (SD 12.1) | Baseline | mPAP | 12 | 62.8 | SD 13.7 | Response to iloprost
Yang, 2012^169^ Patients with Eisenmenger syndrome (N=12) Fair | Mean 33.2 (SD 12.1) | Mean followup 18.6 ± 7.4 mo | mPAP | 12 | 58.9 | SD 11.7 p=0.059 | Response to iloprost

ANP = A-type natriuretic peptide; BNP = B-type natriuretic peptide; CHD = congenital heart disease; CTD = connective tissue disease; CO = cardiac output; cTnT = cardiac troponin T; CVD = collagen vascular disease; FAC = fractional area change; mPAP = mean pulmonary artery pressure; mo = month/months; MPI = myocardial performance index; NR = not reported; PVR = pulmonary vascular resistance; RA = right atrium; RIMP = right index of myocardial performance; RV = right ventricle; SD = standard deviation; SEM = standard error of the mean; sPAP = systolic pulmonary artery pressure; TAPSE = tricuspid annular plane systolic excursion; TRV = tricuspid regurgitant jet velocity; wk=week/weeks; yr=year/years

Table 19 Studies reporting changes in median levels over time

Study Population (N) Quality | Age (Variability) | Timing | Index Test | N | Median | Variability (Range) | Clinical Scenario
Dimitroulas, 2007^97^ Adults with PAH associated with scleroderma (N=10) Good | Median 58 (Range 39 to 74) | Baseline | Natriuretic peptides/BNP | 10 | 474 | | Response to bosentan
Dimitroulas, 2007^97^ Adults with PAH associated with scleroderma (N=10) Good | Median 58 (Range 39 to 74) | 20 wk | Natriuretic peptides/BNP | 10 | 238 | 198–335 (p=0.002 compared with baseline) | Response to bosentan
Halank, 2011^164^ Adults with portopulmonary hypertension (N=14) Fair | Median 57 (Range 46 to 63) | Baseline | NT-proBNP | 11 | 1226 pg/mL | 113 to 2521 | Response to ambrisentan
Halank, 2011^164^ Adults with portopulmonary hypertension (N=14) Fair | Median 57 (Range 46 to 63) | 12 mo | NT-proBNP | 11 | 224 | 59 to 583 | Response to ambrisentan
Ho, 2009^120^ Adults with PAH (N=6) Good | Mean 33 (NR) | Baseline | RIMP/MPI/Tei index | 6 | 0.85 | 0.49 to 1.75 | Response to bosentan
Ho, 2009^120^ Adults with PAH (N=6) Good | Mean 33 (NR) | 6 mo | RIMP/MPI/Tei index | 6 | 0.55 | 0.22 to 0.81 | Response to bosentan
Ho, 2009^120^ Adults with PAH (N=6) Good | Mean 33 (NR) | 1 yr | RIMP/MPI/Tei index | 6 | 0.63 | 0.33 to 1.49 | Response to bosentan
Ho, 2009^120^ Adults with PAH (N=6) Good | Mean 33 (NR) | 18 mo | RIMP/MPI/Tei index | 4 | 0.70 | 0.26 to 1.10 | Response to bosentan
Ho, 2009^120^ Adults with PAH (N=6) Good | Mean 33 (NR) | 2 yr | RIMP/MPI/Tei index | 4 | 0.73 | 0.62 to 1.08 | Response to bosentan
Ho, 2009^120^ Adults with PAH (N=6) Good | Mean 33 (NR) | 30 mo | RIMP/MPI/Tei index | 4 | 0.67 | 0.45 to 1.16 | Response to bosentan
Ho, 2009^120^ Adults with PAH (N=6) Good | Mean 33 (NR) | Baseline | sPAP | 6 | 98 | 50 to 163 | Response to bosentan
Ho, 2009^120^ Adults with PAH (N=6) Good | Mean 33 (NR) | 6 mo | sPAP | 6 | 103 | 37 to 142 | Response to bosentan
Ho, 2009^120^ Adults with PAH (N=6) Good | Mean 33 (NR) | 1 yr | sPAP | 6 | 92 | 42 to 127 | Response to bosentan
Ho, 2009^120^ Adults with PAH (N=6) Good | Mean 33 (NR) | 18 mo | sPAP | 4 | 118 | 28 to 143 | Response to bosentan
Ho, 2009^120^ Adults with PAH (N=6) Good | Mean 33 (NR) | 2 yr | sPAP | 4 | 118 | 61 to 136 | Response to bosentan
Ho, 2009^120^ Adults with PAH (N=6) Good | Mean 33 (NR) | 30 mo | sPAP | 4 | 108 | 87 to 117 | Response to bosentan
Ho, 2009^120^ Adults with PAH (N=6) Good | Mean 33 (NR) | Baseline | Fractional area change | 6 | 22 | 13 to 28 | Response to bosentan
Ho, 2009^120^ Adults with PAH (N=6) Good | Mean 33 (NR) | 6 mo | Fractional area change | 6 | 27 | 15 to 54 | Response to bosentan
Ho, 2009^120^ Adults with PAH (N=6) Good | Mean 33 (NR) | 1 yr | Fractional area change | 6 | 26 | 9 to 49 | Response to bosentan
Ho, 2009^120^ Adults with PAH (N=6) Good | Mean 33 (NR) | 18 mo | Fractional area change | 4 | 35 | 26 to 53 | Response to bosentan
Ho, 2009^120^ Adults with PAH (N=6) Good | Mean 33 (NR) | 2 yr | Fractional area change | 4 | 27 | 16 to 33 | Response to bosentan
Ho, 2009^120^ Adults with PAH (N=6) Good | Mean 33 (NR) | 30 mo | Fractional area change | 4 | 21 | 19 to 45 | Response to bosentan
Ho, 2009^120^ Adults with PAH (N=6) Good | Mean 33 (NR) | Baseline | Natriuretic peptides/BNP | 6 | 224 | 20 to 169 | Response to bosentan
Ho, 2009^120^ Adults with PAH (N=6) Good | Mean 33 (NR) | 6 mo | Natriuretic peptides/BNP | 6 | 111 | 13 to 231 | Response to bosentan
Ho, 2009^120^ Adults with PAH (N=6) Good | Mean 33 (NR) | 1 yr | Natriuretic peptides/BNP | 6 | 136 | 5 to 249 | Response to bosentan
Ho, 2009^120^ Adults with PAH (N=6) Good | Mean 33 (NR) | 18 mo | Natriuretic peptides/BNP | 4 | 215 | 14 to 352 | Response to bosentan
Ho, 2009^120^ Adults with PAH (N=6) Good | Mean 33 (NR) | 2 yr | Natriuretic peptides/BNP | 4 | 193 | 92 to 293 | Response to bosentan
Ho, 2009^120^ Adults with PAH (N=6) Good | Mean 33 (NR) | 30 mo | Natriuretic peptides/BNP | 4 | 203 | 81 to 376 | Response to bosentan
Ho, 2009^120^ Adults with PAH (N=6) Good | Mean 33 (NR) | Baseline | RVEF | 6 | 30 | 14 to 35 | Response to bosentan
Ho, 2009^120^ Adults with PAH (N=6) Good | Mean 33 (NR) | 6 mo | RVEF | 6 | 39 | 17 to 71 | Response to bosentan
Ho, 2009^120^ Adults with PAH (N=6) Good | Mean 33 (NR) | 1 yr | RVEF | 6 | 35 | 15 to 60 | Response to bosentan
Ho, 2009^120^ Adults with PAH (N=6) Good | Mean 33 (NR) | 1 yr | RVEF | 6 | 32 | 15 to 83 | Response to bosentan
Ho, 2009^120^ Adults with PAH (N=6) Good | Mean 33 (NR) | 18 mo | RVEF | 4 | 45 | 31 to 77 | Response to bosentan
Ho, 2009^120^ Adults with PAH (N=6) Good | Mean 33 (NR) | 2 yr | RVEF | 4 | 38 | 20 to 50 | Response to bosentan
Ho, 2009^120^ Adults with PAH (N=6) Good | Mean 33 (NR) | 30 mo | RVEF | 4 | 28 | 24 to 62 | Response to bosentan
Kopec, 2012^166^ Adults with Eisenmenger syndrome (N=7) Fair | Median 40.0 (Range 30.0 to 56.0) | Baseline | Natriuretic peptides/BNP | 7 | 260.8 | 190.6 to 502.9 | Response to bosentan
Kopec, 2012^166^ Adults with Eisenmenger syndrome (N=7) Fair | Median 40.0 (Range 30.0 to 56.0) | 3 mo | Natriuretic peptides/BNP | 7 | 169 | 144.9 to 341.8 p=0.02 | Response to bosentan
Kopec, 2012^166^ Adults with Eisenmenger syndrome (N=7) Fair | Median 40.0 (Range 30.0 to 56.0) | Baseline | Endothelin-1 | 7 | 2.5 | 1.7 to 2.8 | Response to bosentan
Kopec, 2012^166^ Adults with Eisenmenger syndrome (N=7) Fair | Median 40.0 (Range 30.0 to 56.0) | 3 mo | Endothelin-1 | 7 | 4.5 | 2.6 to 5.3 p=0.02 | Response to bosentan

BNP = B-type natriuretic peptide; mo = month/months; NR = not reported; RVEF = right ventricle ejection fraction; wk = week/weeks; yr = year/years

Due to the small number and heterogeneity of these studies in regard to index test and type of therapy, we were unable to perform meta-analysis on these data. While a few studies found changes in biomarkers or echocardiographic parameters in response to various treatments, there were insufficient data to quantitatively assess overall response or to recommend use of these markers as surrogate outcomes measures. Many of these studies also evaluated changes in patient outcomes in response to therapy, but there were no data to correlate change in biomarkers or echocardiographic parameters with these changes in outcomes.

Of the 13 studies that assessed mean values of BNP in response to various therapies (prostanoids, sildenafil, endothelin receptor antagonists, or “standard therapy”), most showed a decrease in BNP levels by approximately half after 3 to 6 months of therapy (Table 18).93,96,106,119,124,130,133,136,167,168 Studies with longer followup times showed that the lower BNP levels remained stable throughout the course of followup.93,119,136 One study with mean followup of 9 months showed no change in BNP levels in response to tadalafil.172 Another study actually showed an increase in BNP levels after a mean followup duration of 20 months when patients were transitioned from bosentan to ambrisentan but a decrease in levels when ambrisentan was started as the first line endothelin receptor antagonist therapy.173

Four of five studies assessing changes in mean sPAP showed decreased values in response to tadalafil after 1 month of followup,88 bosentan after 9 months of followup,165 or epoprostenol after 6 to 24 months of followup.137,146 One study showed no change in mean sPAP levels for unspecified monotherapy after 18 month followup or combination therapy after 12 months of followup.121

In three studies, mean RIMP/MPI/Tei index did not change appreciably over time following treatment with bosentan/iloprost101 or epoprostenol137,146 after 5 to 23 months of followup. Five studies showed no change in mean RV size after treatment with epoprostenol for 15 to 23 months of followup,93,137 bosentan for 24 months of followup,165 iloprost after 18 months of followup,169 or tadalafil after 9 months of followup.172 Mean TRV decreased slightly in one study after 22 months of treatment with epoprostenol.137 Two studies showed no change in mean TRV over 6 months of treatment with either bosentan or ambrisentan133 or 9 months of treatment with tadalafil.172 There was a slight decrease in mean TAPSE value following 15 months of epoprostenol therapy in one study.93 Studies showed no change in mean levels of endothelin-1 in response to epoprostenol after 3 months,123 FAC in response to epoprostenol after 15 months,93 or RA size after epoprostenol or bosentan for 24 months.138,165 In one study, mean nitric oxide level decreased significantly over 1 year of treatment with bosentan.92

The four studies that assessed change in median levels of BNP in response to therapy with bosentan showed decrease by approximately half after 3 to 12 months of therapy (Table 19).97,120,164,166 However, one of these studies subsequently showed increasing levels of BNP after 30 months of therapy.120 One study showed an overall moderate decrease in median RIMP/MPI/Tei index levels after 30 months of therapy but no significant change in median values of sPAP, FAC, or RVEF after 30 months of therapy.120

Seven studies assessed mean change from baseline for BNP or various echocardiographic parameters (Table 20). One study evaluated response to therapy with epoprostenol over 3 months and showed mild increase in RV size, decrease in FAC, and minimal decrease in TR jet velocity.116 Another study evaluated response to 4 months of therapy with bosentan or sildenafil and showed—in response to bosentan—decrease in RV size, minimal increase in CI, minimal decrease in RIMP/MPI/Tei index, increase in RA size, decrease in BNP, and decrease in RV size, and—in response to sildenafil—greater decrease in RV size, RIMP/MPI/Tei index and BNP and decrease in RA size but similar response in CI.156 Another study showed decrease in mean BNP levels after 6 months of therapy with ambrisentan.171 Two studies showed decrease in median levels of BNP in response to treprostinil after 6 weeks with some attenuation of response after 3 months131 and after 6 months of therapy with ambrisentan.131 Three studies showed a decrease from baseline for mean levels of mPAP, one after 3 months therapy with bosentan,94 one after 3 months therapy with epoprostenol85 and one with persistently declining levels during 3 years of therapy with ambrisentan.174

Table 20 Studies reporting mean or median change from baseline

Study Population (N) Quality | Age (Variability) | Timing | Result | Index Test | N | Results | Variability | Clinical Scenario
Badesch, 2012^171^ Adults with PAH (N=224) Good | Mean 55 (SD 16) | Baseline | Mean | Natriuretic peptides/BNP | 224 | 335 | SD 413 | Response to ambrisentan
Badesch, 2012^171^ Adults with PAH (N=224) Good | Mean 55 (SD 16) | 6 mo | Mean change | Natriuretic peptides/BNP | 224 | −26 | 95% CI −34 to −16 | Response to ambrisentan
Barst, 1996^85^ Adults with PPH (N=81) Good | NR for cohort | 3 mo | Mean change | mPAP | 41 | −4.8 | SE 1.3 | Response to epoprostenol
Channick, 2001^94^ Adults with PPH or PAH associated with scleroderma (N=32) Good | NR for cohort | 3 mo | Mean change | mPAP | 20 | −1.6 | SE 1.2 | Response to bosentan
Hinderliter, 1997^116^ Adults with PPH (N=81) Fair | NR for cohort | Baseline | Mean | RV size | 38 | 21.2 | SE 0.7 | Response to epoprostenol
Hinderliter, 1997^116^ Adults with PPH (N=81) Fair | NR for cohort | Baseline | Mean | Fractional area change | 38 | 19.2 | SE 1.2 | Response to epoprostenol
Hinderliter, 1997^116^ Adults with PPH (N=81) Fair | NR for cohort | Baseline | Mean | TR jet velocity | 36 | 4.3 | SE 0.1 | Response to epoprostenol
Hinderliter, 1997^116^ Adults with PPH (N=81) Fair | NR for cohort | 3 mo | Median change | RV size | 33 | 0.4 | | Response to epoprostenol
Hinderliter, 1997^116^ Adults with PPH (N=81) Fair | NR for cohort | 3 mo | Median change | Fractional area change | 33 | −2.2 | | Response to epoprostenol
Hinderliter, 1997^116^ Adults with PPH (N=81) Fair | NR for cohort | 3 mo | Median change | TR jet velocity | 32 | −0.04 | | Response to epoprostenol
McLaughlin, 2010^131^ Adults with PAH (N=235) Good | Mean 54 (Range 18 to 75) | 6 wk | Median change | Natriuretic peptides/BNP | 86 | −71 | p<0.0003 | Response to treprostinil
McLaughlin, 2010^131^ Adults with PAH (N=235) Good | Mean 54 (Range 18 to 75) | 3mo | Median change | Natriuretic peptides/BNP | 73 | −57 | IQR −396.0 to 34.0 | Response to treprostinil
Wilkins, 2005^156^ Adults with IPAH or PAH associated with CTD (N=26) Good | NR for cohort | 4 mo | Mean change | RV size | 12 | −3 | 95% CI −7.5 to 1.5 | Response to bosentan
Wilkins, 2005^156^ Adults with IPAH or PAH associated with CTD (N=26) Good | NR for cohort | 4 mo | Mean change | Cardiac Index | 12 | 0.3 | 95% CI 0.1 to 0.4 p=0.01 | Response to bosentan
Wilkins, 2005^156^ Adults with IPAH or PAH associated with CTD (N=26) Good | NR for cohort | 4 mo | Mean change | RIMP/MPI/Tei Index | 12 | −0.02 | 95% CI −0.1 to 0.11 | Response to bosentan
Wilkins, 2005^156^ Adults with IPAH or PAH associated with CTD (N=26) Good | NR for cohort | 4 mo | Mean change | RA size | 12 | 4 | 95% CI −16 to 23 | Response to bosentan
Wilkins, 2005^156^ Adults with IPAH or PAH associated with CTD (N=26) Good | NR for cohort | 4 mo | Mean change | Natriuretic peptides/BNP | 12 | −5.9 | 95% CI −35 to 24 | Response to bosentan
Wilkins, 2005^156^ Adults with IPAH or PAH associated with CTD (N=26) Good | NR for cohort | 4 mo | Mean change | RV size | 13 | −8.8 | 95% CI −16 to −2 p=0.05 | Response to sildenafil
Wilkins, 2005^156^ Adults with IPAH or PAH associated with CTD (N=26) Good | NR for cohort | 4 mo | Mean change | Cardiac Index | 13 | 0.3 | 95% CI 0.1 to 0.4 p=0.01 | Response to sildenafil
Wilkins, 2005^156^ Adults with IPAH or PAH associated with CTD (N=26) Good | NR for cohort | 4 mo | Mean change | RIMP/MPI/Tei Index | 13 | −0.11 | 95% CI −0.23 to 0.01 | Response to sildenafil
Wilkins, 2005^156^ Adults with IPAH or PAH associated with CTD (N=26) Good | NR for cohort | 4 mo | Mean change | RA size | 13 | −4 | 95% CI −19 to 12 | Response to sildenafil
Wilkins, 2005^156^ Adults with IPAH or PAH associated with CTD (N=26) Good | NR for cohort | 4 mo | Mean change | Natriuretic peptides/BNP | 13 | −19.4 | 95% CI −34 to −5 | Response to sildenafil
Yoshida, 2012^174^ Adults with PAH (N=21) Fair | Mean 45.6 (SD 12.6) | Baseline | Mean | Natriuretic peptides/ | 21 | 191.1 | SD 241.4 | Response to ambrisentan
Yoshida, 2012^174^ Adults with PAH (N=21) Fair | Mean 45.6 (SD 12.6) | Baseline | Mean | mPAP | 20 | 48.1 | SD 17 | Response to ambrisentan
Yoshida, 2012^174^ Adults with PAH (N=21) Fair | Mean 45.6 (SD 12.6) | 6 mo | Mean change | Natriuretic peptides/ | 20 | −109.5 | SD 170.5 | Response to ambrisentan
Yoshida, 2012^174^ Adults with PAH (N=21) Fair | Mean 45.6 (SD 12.6) | 6 mo | Mean change | mPAP | 21 | −10 | SD 7.4 95% CI −13.5 to −6.4 | Response to ambrisentan
Yoshida, 2012^174^ Adults with PAH (N=21) Fair | Mean 45.6 (SD 12.6) | 1 yr | Mean change | Natriuretic peptides/ | 21 | −70.4 | SD 211.5 | Response to ambrisentan
Yoshida, 2012^174^ Adults with PAH (N=21) Fair | Mean 45.6 (SD 12.6) | 1 yr | Mean change | mPAP | 19 | −7.1 | SD 10.1 95% CI −11.9 to −2.2 | Response to ambrisentan
Yoshida, 2012^174^ Adults with PAH (N=21) Fair | Mean 45.6 (SD 12.6) | 2 yr | Mean change | Natriuretic peptides/ | 19 | −117.1 | SD 183.8 | Response to ambrisentan
Yoshida, 2012^174^ Adults with PAH (N=21) Fair | Mean 45.6 (SD 12.6) | 2 yr | Mean change | mPAP | 16 | −10.9 | SD 10.8 95% CI −16.6 to −5.1 | Response to ambrisentan
Yoshida, 2012^174^ Adults with PAH (N=21) Fair | Mean 45.6 (SD 12.6) | 3 yr | Mean change | Natriuretic peptides/ | 6 | −146.5 | SD 218.6 | Response to ambrisentan
Yoshida, 2012^174^ Adults with PAH (N=21) Fair | Mean 45.6 (SD 12.6) | 3 yr | Mean change | mPAP | 6 | −13.9 | SD 8.9 95% CI −23.2 to −4.5 | Response to ambrisentan

BNP = B-type natriuretic peptide; CI = confidence interval; IQR = interquartile range; mPAP = mean pulmonary artery pressure; mo = month/months; MPI = myocardial performance index; NR = not reported; PVR = pulmonary vascular resistance; RA = right atrium; RIMP = right index of myocardial performance; RV = right ventricle; RVEF = right ventricle ejection fraction; SD = standard deviation; SEM = standard error of the mean; sPAP = systolic pulmonary artery pressure; TAPSE = tricuspid annular plane systolic excursion; TRV = tricuspid regurgitant jet velocity; wk = week/weeks; yr = year/years

### Summary Strength of Evidence for KQ 2

The strength of evidence ratings for the most commonly reported biomarkers and echocardiographic parameters are summarized in Table 21 (assessment of prognostic value) and Table 22 (assessment of predictive value).

Table 21 Summary strength of evidence for KQ 2: assessment of prognostic value

Comparison | Number of Studies (Patients) | Domains | | | | Strength of Evidence Correlation Coefficient (95% CI)
Comparison | Number of Studies (Patients) | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Correlation Coefficient (95% CI)
BNP compared with RHC-mPAP | 14 (606) | Low (12) Moderate (1) High (1) | Consistent | Indirect | Precise | SOE = Moderate 0.39 (0.31 to 0.47) Serum BNP level shows moderate correlation with mPAP
BNP compared with RHC-PVR | 13 (684) | Low (11) Moderate (1) High (1) | Inconsistent | Indirect | Precise | SOE = Low 0.46 (0.31 to 0.59) Serum BNP level shows moderate correlation with PVR
BNP compared with RHC-RAP | 12 (645) | Low (11) Moderate (1) | Consistent | Indirect | Precise | SOE = Moderate 0.47 (0.40 to 0.54) Serum BNP level shows moderate correlation with RAP
BNP compared with RHC-CI | 10 (550) | Low (9) Moderate (1) | Inconsistent | Indirect | Precise | SOE = Low −0.42 (−0.54 to −0,28) Serum BNP level shows negative moderate correlation with cardiac index
BNP compared with RHC-PCWP | 5 (319) | Low (4) High (1) | Consistent | Indirect | Imprecise | SOE = Low 0.16 (0.01 to 0.31) Serum BNP level shows poor correlation with PCWP
BNP compared with 6MWD (absolute) | 9 (484) | Low (8) High (1) | Inconsistent | Direct | Precise | SOE = Moderate −0.46 (−0.55 to −0.35) Serum BNP level shows negative moderate correlation with 6MWD
Echocardiography-derived sPAP compared with RHC-sPAP | 9 (362) | Low (6) Moderate (3) | Inconsistent | Indirect | Precise | SOE = Low 0.76 (0.53 to 0.89) sPAP estimated by echocardiography shows good correlation with sPAP from RHC

6MWD = 6-minute walk distance; BNP = B-type natriuretic peptide; CI = confidence interval; PCWP = pulmonary capillary wedge pressure; PVR = pulmonary vascular resistance; RAP = right atrial pressure; RHC = right heart catheterization; SOE = strength of evidence; sPAP = systolic pulmonary artery pressure

Table 22 Summary strength of evidence for KQ 2: assessment of predictive value

Comparison | Number of Studies (Patients) | Domains | | | | Strength of Evidence Hazard Ratio (95% CI)
Comparison | Number of Studies (Patients) | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Hazard Ratio (95% CI)
BNP (log-transformed) | 6 (407) | Low (5) Moderate (1) | Consistent | Direct | Imprecise | SOE = Moderate 2.42 (1.72 to 3.41)) Increase in log-transformed BNP level is a good predictor of mortality
Pericardial effusion | 8 (2590) | Low (5) Moderate (3) | Inconsistent | Direct | Imprecise | SOE = Moderate 2.43 (1.57 to 3.77) Presence of pericardial effusion is a strong predictor of mortality, although there was wide variability in results for this measure
RA size | 4 (242) | Low (2) Moderate (2) | Inconsistent | Direct | Precise | SOE = Moderate 1.06 (1.01 to 1.10) RA size is a predictor of mortality
FAC | 4 (242) | Low (2) Moderate (2) | Consistent | Direct | Precise | SOE = Moderate 0.98 (0.96 to 1.01) FAC is a poor predictor of mortality
Uric acid | 4 (246) | Low (3) Moderate (1) | Inconsistent | Direct | Imprecise | SOE = Low 1.01 (1.00 to 1.01) Small increase in mortality but imprecision of estimates limit these data
TAPSE | 4 (251) | Low (3) Moderate (2) | Inconsistent | Direct | Imprecise | SOE = Insufficient Inconsistent results between studies lead to uncertainty

BNP = B-type natriuretic peptide; CI = confidence interval; FAC = fractional area change; RA = right atrium; RAP = right atrial pressure; SOE=strength of evidence

## KQ 3 Pharmacotherapy for PAH

For patients with PAH, what are the comparative effectiveness and safety of monotherapy or combination therapy for PAH using calcium channel blockers, prostanoids, endothelin antagonists, or phosphodiesterase inhibitors on intermediate-term and long-term patient outcomes?

### Key Points

- In patients who have been receiving monotherapy, combination therapy appears to be moderately more effective than continuation of monotherapy for improving 6-minute walk distance (6MWD), with a magnitude of effect that is approximately equal to the estimated minimal important difference (MID) of 6MWD for PAH of 33 meters (low strength of evidence).
- We did not identify any eligible studies that evaluated the comparative effectiveness of calcium channel blockers on intermediate-term and long-term patient outcomes, or that randomized treatment-naïve patients to monotherapy versus combination therapy, or that directly compared two drug classes.
- Although we did not intend to exclude studies of children, the inclusion criterion requiring reporting intermediate-term and long-term patient outcomes had the effect of eliminating randomized clinical trials of children with PAH.
- Prostanoids were associated with lower mortality when compared with standard therapy or placebo (low strength of evidence). Current evidence is inconclusive regarding a reduction in mortality associated with treatment with endothelin antagonists or phosphodiesterase inhibitors (insufficient strength of evidence).
- Endothelin antagonists, phosphodiesterase inhibitors, and prostanoids were all associated with improved 6MWD after 8 to 16 weeks of therapy with a magnitude of effect that is approximately equal to the estimated minimal important difference (MID) of 6MWD for PAH of 33 meters (moderate strength of evidence).
- Endothelin antagonists and phosphodiesterase inhibitors were associated with lower incidence of hospitalization when compared with standard therapy or placebo (moderate strength of evidence). Current evidence is inconclusive regarding a reduction in hospitalization associated with treatment with prostanoids (insufficient strength of evidence).
- Endothelin antagonists, phosphodiesterase inhibitors, and prostanoids were associated with statistically significant improvements in most or all hemodynamic measures such as PVR, mPAP, and cardiac index (low strength of evidence) compared with placebo or standard therapy. The clinical significance of the magnitude of the observed changes in these intermediate outcomes is unclear.
- Among commonly reported adverse events, there was a higher incidence of jaw pain associated with aerosolized prostanoid treatment compared with placebo (high strength of evidence) and cough associated with aerosolized prostanoids versus placebo (high strength of evidence). In addition, headache was associated with phosphodiesterase inhibitors compared with placebo or standard therapy (moderate strength of evidence), and flushing was associated with phosphodiesterase inhibitors (moderate strength of evidence) and aerosolized prostanoids (moderate strength of evidence) compared with placebo or standard therapy.

### Description of Included Studies

We identified 37 unique studies involving a total of 4192 patients that evaluated the comparative effectiveness and safety of monotherapy or combination therapy for PAH. Of these studies, 28 were RCTs and 9 were nonrandomized comparative observational studies. We describe the findings from these studies separately by study design below.

#### Study Characteristics

##### Randomized Controlled Trials

Twenty-eight RCTs involving a total of 3613 patients evaluated the comparative effectiveness and safety of monotherapy or combination therapy for PAH.85,88,94,106,131,156,181–200 Of these, 28 RCTs, 18 (64%) were rated good quality, 9 (32%) fair quality, and 1 (4%) was poor quality. Nineteen studies (68%) were funded by industry, one by private foundation, one by government and private funding, one by private and industry funding, one by industry and “other” funding, and five did not clearly report funding sources.

Study characteristics for each of the 28 RCTs relevant to KQ 3 are presented in Table 23. Studies are organized alphabetically by drug and include patient population, size, and quality; study arms and size; trial duration and followup; and outcome measures. The mean patient ages ranged from 28 to 50 years old. Twenty studies enrolled patients with PAH,85,88,106,131,156,181,182,184,186–189,192,193,196–200 four studies enrolled patients with PAH associated with systemic sclerosis (formerly scleroderma),94,185,194 and two studies enrolled patients with Eisenmenger syndrome.183,195 Two studies enrolled a minority of patients with PH other than PAH: one included patients with chronic thromboembolic PH (28%);190 and another included patients with PH owing either to lung disease or chronic thromboembolic PH (37%).191

Table 23 Study characteristics table for KQ 3 (RCTs)

Study Population (N) Quality | Study Arms (N) | Trial Duration (Weeks) | Followup Assessments (Weeks) | Outcome Measures
AMBRISENTAN
Individual Drug Studies
Galie, 2008^106^ ARIES-1 (US, Mexico, South America, Australia, and Europe) PAH (N=201) Good | - Ambrisentan 5 mg daily (N=67); - Ambrisentan 10 mg daily (N=67); - Placebo (N=67) | 12 | 4, 8, 12, 48 | - Mortality; - 6MWD; - Dyspnea; - Functional class; - Quality of life; - Hospitalization; - BNP; - Adverse events
Galie, 2008^106^ ARIES-2 (Europe, Israel, and South America) PAH (N=192) Good | - Ambrisentan 2.5 mg daily (N=64); - Ambrisentan 5 mg daily (N=63); - Placebo (N=65) | 12 | 4, 8, 12, 48 | - Mortality; - 6MWD; - Dyspnea; - Functional class; - Quality of life; - Hospitalization; - BNP; - Adverse events
BOSENTAN
Individual Drug Studies
Barst, 2010^185^ ASSET-1 SCD with PAH (N=14) Fair | - Bosentan 62.5 mg 2 times daily, then 125 mg 2 times daily (N=6); - Placebo (N=8) | 16 | 16 | - Mortality; - 6MWD; - RHC
Barst, 2010^185^ ASSET-2 PH (N=12) Fair | - Bosentan 62.5 mg 2 times daily, then 125 mg 2 times daily (N=5); - Placebo (N=7) | 16 | 16 | - Mortality; - 6MWD; - RHC
Channick, 2001^94^ PPH or PH due to SCD (N=32) Good | - Bosentan 62.5 mg 2 times daily, then 125 mg 2 times daily (N=21); - Placebo (N=11) | 12 | 4, 8, 12, 20, 28 | - 6MWD; - Dyspnea; - Functional class; - Transplantation; - RHC; - Adverse events
Galie, 2006^183^ BREATHE-5 Eisenmenger syndrome (N=54) Good | - Bosentan 62.5 mg 2 times daily, then 125 mg 2 times daily (N=37); - Placebo (N=17) | 4 | 4 | - 6MWD; - Functional class; - RHC; - Adverse events
Galie, 2008^184^ EARLY PAH (N=185) Good | - Bosentan 62.5 mg 2 times daily, then 125 mg 2 times daily (N=93); - Placebo (N=92) | 24 | 24 | - Mortality^a^; - 6MWD^a^; - Dyspnea^a^; - Functional class^a^; - Quality of life^a^; - Hospitalization^a^; - RHC^a^; - Adverse events^a^
Rubin, 2002^182^ BREATHE PAH (N=213) Good | - Bosentan 62.5 mg 2 times daily, then 125 mg 2 times daily (N=74); - Bosentan 62.5 mg 2 times daily, then 250 mg 2 times daily (N=70); - Placebo (N=69) | 12 | 4, 8, 16 | - Mortality; - 6MWD; - Dyspnea; - Functional class; - Hospitalization; - Echocardiography; - Adverse events
Direct Drug Comparison Studies
Wilkins, 2005^156^ SERAPH PAH (N=26) Good | - Bosentan 62.5 mg 2 times daily, then 125 mg 2 times daily (N=12); - Sildenafil 50 mg 2 times daily, then 50 mg 3 times daily (N=14) | 16 | 16 | - Mortality; - 6MWD; - Quality of life; - Right ventricular dysfunction; - Echocardiography; - BNP
Combination Drug Studies
Humbert, 2004^186^ BREATHE-2 PAH (N=33) Good | - Epoprostenol + bosentan 62.5 mg 2 times daily, then 125 mg 2 times daily (N=22); - Epoprostenol + placebo (N=11) | 16 | 16 | - 6MWD; - Dyspnea; - Functional class; - Hospitalization; - Right heart failure; - RHC; - Adverse events
EPOPROSTENOL
Individual Drug Studies
Badesch, 2000^194^ PH associated with SCD spectrum of disease (N=111) Fair | - Epoprostenol ≤2 ng/kg, then adjusted (N=56); - Conventional therapy only (N=55) | 12 | 1, 6, 12 | - Mortality; - 6MWD; - Dyspnea; - RHC; - Adverse events
Barst, 1996^85^ PPH (N=81) Good | - Epoprostenol 4 ng/kg, then adjusted (N=41); - Conventional therapy only (N=40) | 12 | 1, 6, 12 | - Mortality; - 6MWD; - Quality of life; - Transplantation; - RHC; - Adverse events
Rubin, 1990^181^ PPH (N=23) Good | - Intravenous epoprostenol 1–2 ng/kg per minute initially, then increased as tolerated (N=11); - Conventional therapy (N=12) | 8 | 8 | - Mortality; - 6MWD; - RHC; - Adverse events
ILOPROST
Individual Drug Studies
Olschewski, 2002^190^ Severe PAH or chronic thromboembolic PH (N=203) Good | - Aerosolized iloprost (N=101); - Placebo (N=102) | 12 | 4, 8, 12 | - Mortality; - 6MWD; - Dyspnea; - Functional class; - Quality of life; - Transplantation; - Right ventricular dysfunction; - RHC; - Adverse events
Olschewski, 2010^191^ AIR IPAH or other PH (N=63) Fair | - Aerosolized iloprost (N=30); - Conventional therapy only (N=33) | 12 | 12, 104 | - Mortality; - 6MWD; - Dyspnea; - Functional class; - Quality of life; - Right heart failure; - RHC; - Adverse events
Combination Drug Studies
Hoeper, 2006^192^ COMBI IPAH (N=40) Fair | - Bosentan 125 mg 2 times daily + aerosolized iloprost (N=19); - Bosentan 125 mg (N=21) | 12 | 6, 12 | - 6MWD; - Adverse events
McLaughlin, 2006^193^ PAH (N=67) Good | - Bosentan + aerosolized iloprost (N=34); - Bosentan + placebo (N=33) | 12 | 4, 8, 12 | - 6MWD; - Dyspnea; - Functional class; - Hospitalization; - RHC; - Adverse events
SILDENAFIL
Individual Drug Studies
Barst, 2011^188^ STARTS-1 PAH (N=234) Fair | - Low-dose sildenafil (N=42); - Medium-dose sildenafil (N=55); - High-dose sildenafil (N=77); - Placebo (N=60) | 16 | 16, >156 | - Mortality; - Functional class; - Quality of life; - RHC; - Adverse events
Galie, 2005^187^ SUPER PAH (N=277) Good | - Sildenafil 20 mg 3 times daily (N=69); - Sildenafil 40 mg 3 times daily (N=67); - Sildenafil 80 mg 3 times daily (N=71); - Placebo (N=70) | 12 | 4, 8, 12, 52, 156 | - Mortality; - 6MWD; - Dyspnea; - Hospitalization; - Adverse events; - RHC
Combination Drug Studies
Simonneau, 2008^189^ PACES PAH (N=267) Good | - Sildenafil 20 mg 3 times daily + epoprostenol, then up to 80 mg 3 times daily + epoprostenol (N=134); - Placebo + epoprostenol (N=133) | 16 | 4, 8, 12, 16 | - Mortality; - Dyspnea; - Quality of life; - Hospitalization; - Transplantation; - Adverse events
TADALAFIL
Individual Drug Studies
Bharani, 2007^88^ PAH (N=11) Fair | - Tadalafil 20 mg daily (N=11); - Placebo 20 mg daily (N=11) | 4 | 4 | - 6MWD^a^; - Dyspnea^a^; - Functional class^a^; - Echocardiography^a^
Galie, 2009^196^ PHIRST PAH (N=405) Good | - Tadalafil 2.5 mg daily (N=82); - Tadalafil 10 mg daily (N=82); - Tadalafil 20 mg daily (N=80); - Tadalafil 40 mg daily (N=79); - Placebo (N=82)^b^ | 16 | 4, 8, 12, 16 | - Mortality; - 6MWD; - Functional class; - Hospitalization; - RHC; - Adverse events
Mukhopadhyay, 2011^195^ Eisenmenger syndrome (N=28) Fair | - Tadalafil 40 mg daily (N=28); - Placebo (N=28) | 6 | 6 | - 6MWD^a^; - RHC^a^
TREPROSTINIL
Individual Drug Studies
Hiremath, 2010^199^ TRUST PAH (N=44) Fair | - Intravenous treprostinil 4 ng/kg/min, then adjusted (N=30); - Placebo (N=14) | 12 | 12 | - Mortality; - 6MWD; - Dyspnea; - Functional class; - Adverse events
McLaughlin, 2003^198^ PPH (N=26) Poor | - Subcutaneous treprostinil 2.5–5.0 ng/kg/min, then adjusted (N=17); - Placebo (N=9) | 8 | 8 | - 6MWD^a^; - Dyspnea^a^; - Adverse events^a^
Simonneau, 2002^197^ PAH (N=470) Good | - Subcutaneous treprostinil 1.25 ng/kg/min, then adjusted (N=233); - Placebo (N=236) | 12 | 12 | - Mortality; - 6MWD; - Dyspnea; - Quality of life; - Transplantation; - Adverse events
Combination Drug Studies
McLaughlin, 2010^131^ TRIUMPH 1 Severe PAH (N=235) Good | - Aerosolized treprostinil 18 mcg 4 times daily, gradually increased to 54 mcg+ bosentan/ sildenafil (N=115); - Placebo + bosentan/sildenafil (N=120) | 12 | 6, 12 | - Mortality; - 6MWD; - Dyspnea; - Functional class; - Quality of life; - Hospitalization; - Transplantation; - BNP; - Adverse events
VARDENAFIL
Individual Drug Studies
Jing, 2011^200^ EVALUATION PAH (N=66) Good | - Vardenafil 5 mg daily, then 5 mg 2 times daily (N=44); - Placebo (N=22) | 12 | 12, 24 | - Mortality; - 6MWD; - Dyspnea; - Functional class; - Hospitalization; - RHC; - Adverse events

6MWD = 6 minute walk distance; IPAH = idiopathic PAH; mg = milligram; PAH = pulmonary arterial hypertension; PH = pulmonary hypertension; PPH = Primary pulmonary hypertension; RHC = right heart catheterization; SCD = scleroderma

a Outcome not assessed at 12 or 16 weeks.

b 53 percent of patients received bosentan as background therapy.

Twenty-one studies compared a single drug (monotherapy) with placebo or standard therapy and included the following drugs: bosentan (6 studies), sildenafil (2), iloprost (2), epoprostenol (3), tadalafil (3), ambrisentan (2), treprostinil (3), and vardenafil (1). For the purposes of this analysis, the standard therapy arms were grouped with the placebo arms. Standard therapies included supportive therapy (diuretics, oxygen, digoxin, oral anticoagulants) with or without calcium channel blockers, but not including newer specific vasodilator medications. One study was a head-to-head comparison of bosentan and sildenafil. The remaining five studies randomized patients who had previously received monotherapy to either continued monotherapy with that drug or continued therapy with that drug plus the addition of a second drug. For the purpose of this report, we consider these studies to represent a comparison of combination therapy with monotherapy—with the understanding that this study design does not address the question of whether initiating two drugs is superior to initiating a single drug to treatment-naïve patients.

The remaining five studies compared combination therapy with monotherapy: intravenous (IV) epoprostenol plus bosentan versus IV epoprostenol plus placebo, sildenafil plus IV epoprostenol versus IV epoprostenol plus placebo, bosentan plus aerosolized iloprost versus bosentan, bosentan plus aerosolized iloprost versus bosentan plus placebo, and aerosolized treprostinil plus bosentan or sildenafil versus bosentan or sildenafil plus placebo. We did not identify any eligible studies published after 1990 that evaluated the safety or efficacy of calcium channel blockers on intermediate-term or long-term patient outcomes.

Most studies (85%) were multicenter trials; three were single-center trials, and four did not report the number of centers. Study locations included Europe (19 studies), United States (15), Asia (8), Canada (6), Australia or New Zealand (6), United Kingdom (4), South America (4), Israel (3), Mexico (3), Central America (2), Africa (1), and unreported or unclear setting (6).

The studies reported the following outcomes: 6MWD (27 studies), mortality (21), dyspnea (17), RHC indices (18), functional class (13), hospitalization for worsening PAH (10), quality of life (11), lung transplantation (5), right heart failure or right ventricular dysfunction (4), and brain natriuretic peptide (4). Twenty-one studies reported harms or adverse events.

##### Nonrandomized Comparative Observational Studies

We identified 9 nonrandomized observational studies involving 579 patients.119,201–208 Of these, all were case series studies rated fair quality (Table 24). Four studies were retrospective, and five collected data prospectively. Epoprostenol was evaluated in six studies; iloprost, bosentan, treprostinil, and sildenafil in two studies each. Four studies directly compared two different monotherapies: one study compared bosentan with iloprost, two studies compared epoprostenol with treprostinil, and one study compared epoprostenol with iloprost. One study compared the combination of first-line epoprostenol and bosentan with epoprostenol monotherapy.

Table 24 Study characteristics table for KQ 3 (nonrandomized studies)

Study Study Type Population (N) Quality | Study Arms (N) | Study Review Range | Followup Assessments (Months) | Outcome Measures
Higenbottam, 1993^208^ Prospective case series Severe pulmonary hypertension Fair | - Epoprostenol, initial mean dose 5.2 (0.5) ng/kg/min, then titrated up to mean 18.7 (4.5) ng/kg/min (N=25); - No epoprostenol (N=19) | 6-year period before 1993 | 12, 24, 36, 48 | - Mortality; - Progression to transplant
Fix, 2007^201^ Retrospective case series Porto-pulmonary hypertension (N=36) Fair | - Epoprostenol 1 ng/kg/min, then titrated to mean dose of 29 ng/kg/min (N=19); - Non-epoprostenol (N=17) | 1998–2005 | 2 to 95 | - Mortality; - RHC; - Adverse events
Hoeper, 2007^202^ Retrospective case series Porto-pulmonary hypertension and cirrhosis (N=31) Fair | - Bosentan 62.5 mg 2 times daily × 4 weeks, then 125 mg 2 times daily thereafter (N=18); - Aerosolized iloprost 5 mcg 6 times daily (N=13) | 1999–2004 | 3, 6, 12, 18, 24, 30, 36 | - Mortality; - 6MWD; - Functional class; - Event-free survival; - RHC; - Adverse events
Sastry, 2007^204^ Prospective case series IPAH (N=178) Fair | - Conventional therapy (historical control) (N=39); - Conventional therapy + sildenafil 25–50 mg 3 times daily (N=139) | 1999–2005 | 12, 24, 36, 48, 60 | - Mortality
Jacobs, 2009^119^ Prospective case series IPAH (N=16) Fair | - Epoprostenol titrated to 6–8 ng/kg/min after 1 week (N=6); - Treprostinil gradually increased to 10 ng/kg/min after 1 week, then 20 ng/kg/min after 6 weeks (N=10) | 2002–2007 | 4, 6 | - Mortality; - 6MWD; - Functional class; - Natriuretic peptides; - Adverse events
Reichenberger, 2011^203^ Prospective case series IPAH, PAH, portopulmonary hypertension (N=24) Fair | - Epoprostenol gradually increased to maximum tolerated dose (N=12); - Aerosolized iloprost gradual titration up to 20 mcg per breath, maximum 120 mcg total daily dose (N=12) | NR | 3, 12, 18, 20 | - Mortality; - 6MWD; - Functional class; - RHC; - Progression to transplant; - Adverse events
Zeng, 2011^205^ Retrospective case series IPAH (N=77) Fair | - Conventional therapy (N=26); - Sildenafil 25 mg 3 times daily (N=51) | 2005–2009 | 12, 24, 36 | - Mortality; - 6MWD; - Dyspnea; - RHC; - BNP
Kemp, 2012^206^ Retrospective case series Idiopathic, heritable, or anorexigen-associated PAH (N=69) Fair | - Epoprostenol/bosentan combined (n=23); - Epoprostenol monotherapy (n=46) | 2001–2008 | 96 | - Mortality; - 6MWD; - Functional class; - RHC
Rich, 2012^207^ Prospective cohort PAH (N=120) Fair | - IV Treprostinil in Epoprostenol diluent (n=25); - IV Epoprostenol in Epoprostenol diluent (n=61); - IV Treprostinil in native diluent (n=34) | 2009–2010 | NR (56,563 treatment days) | - Adverse events

6MWD = 6 minute walk distance; BNP = brain natriuretic peptide; IPAH = idiopathic PAH; IV = intravenous; mcg=microgram; NR = not reported; PAH = pulmonary arterial hypertension; RHC = right heart catheterization

We do not discuss these nonrandomized comparative studies further in this report because the size and quality of the nonrandomized comparative studies compared poorly with the randomized trial data we identified. Although these studies offer the potential to address certain between-treatment comparisons that were not evaluated in RCTs and, in some cases, describe a longer duration of followup beyond that reported in the randomized trials, we assessed their limitations of poorly specified comparison (control) treatments and selection bias in treatment allocation combined with a lack of power from small size so severe as to make these data unusable.

### Detailed Synthesis of Randomized Controlled Trials

We report on the outcomes of mortality, 6MWD, hospitalization, PVR, mPAP, cardiac index, and certain adverse reactions (headache, dizziness, diarrhea, peripheral edema, jaw pain, flushing, cough, and infections) for the following comparative analyses of pharmacotherapies:

- Head-to-head comparisons by individual drug, when available
- Monotherapy versus placebo (or monotherapy plus standard therapy vs. standard therapy alone) by individual drug
- Monotherapy versus placebo (or monotherapy plus standard therapy vs. standard therapy alone) by class of drug
- Combination therapy versus monotherapy by individual drug

The latter three comparative analyses are reported in tabular and graphic form in a single forest plot for each outcome. We also conducted meta-analyses and reported summary measures for the analyses by individual drug (e.g., studies of bosentan vs. placebo) and class of drug (e.g., prostacyclin-analogues vs. placebo or standard therapy) whenever there were two or more studies with comparable study arms.

We use the term background treatment for cointerventions that are preexisting and applied to both study arms of an RCT in which a second (new) drug is added to one arm (experimental) but not the other (control). Thus, the trial of iloprost plus bosentan versus bosentan (e.g., COMBI192) would be described as a trial of iloprost with bosentan background therapy and can be construed to examine the efficacy of combination versus monotherapy; it is also relevant to the efficacy of iloprost. In our meta-analyses, we would infer efficacy of iloprost from controlled trials of iloprost both with and without background therapy. This, however, assumes independent and additive effects of the experimental drug relative to any or all of the other background therapies received by the patients enrolled in the trial (including, but not limited to, other PAH-specific drugs, supplemental oxygen, vasodilators, etc.). We did not identify any eligible studies that randomized treatment- naïve patients to monotherapy versus combination therapy, or that randomized treatment-naïve patients to combination therapy versus placebo or standard therapy. In each of the five combination therapy versus monotherapy studies included in this report, combination therapy refers to the step-wise addition of a second drug to existing monotherapy.

#### Mortality

We identified a single head-to-head, double-blind RCT that compared bosentan with sildenafil in patients with PAH.156 One of the 14 patients in the sildenafil group died during the fourteenth week of treatment. There were no deaths among the 12 patients in the bosentan group during the 16-week intervention period. A total of 20 RCTs reported the effects of monotherapy or compared to placebo, standard therapy, or combination therapy for PAH on mortality outcomes. For two of the studies188,193 (including ASSET-2, but not including ASSET-1, both of which were reported in the paper by Barst et al.188), no deaths were reported, so an odds ratio for mortality could not be calculated. Therefore, 18 studies (14 monotherapy and 4 combination therapy) consisting of a total of 3077 patients were included for analysis, as follows:

- 2 studies (represented by 1 article) compared ambrisentan with placebo106
- 3 studies compared bosentan with placebo182,184,185
- 3 studies compared IV epoprostenol with standard therapy85,181,194
- 2 studies compared aerosolized iloprost with placebo190,191
- 1 study compared sildenafil with placebo187
- 1 study compared 4 doses of tadalafil with placebo, with 53% of patients receiving bosentan as background therapy196
- 2 studies compared IV or subcutaneous treprostinil with placebo197,199
- 1 study compared vardenafil with placebo200
- 3 studies compared combination therapy with monotherapy131,186,189

##### Ambrisentan Versus Placebo

Figure 23 shows the forest plot of the odds ratio for mortality for treatment with ambrisentan versus placebo from 2 studies (393 patients). Each of these studies involved two active doses of ambrisentan between 2.5 mg to 10 mg daily with a 5 mg dose used in both studies. Our analysis combined active doses in each study. The duration of treatment was 12 weeks in both studies. The individual odds ratios for the two studies were 0.33 and 0.49, with a summary odds ratio of 0.40 (95% CI, 0.10 to 1.51). The comparative efficacy of ambrisentan in reducing mortality compared with placebo is inconclusive given the small number of trials, the wide confidence intervals, and the observation that the confidence interval includes 1.0.

Figure 23 Forest plot of odds ratio for mortality—ambrisentan versus placebo

CI = confidence interval

Figure 23. Forest plot of odds ratio for mortality—ambrisentan versus placebo. This figure shows the forest plot of the odds ratio for mortality for treatment with ambrisentan versus placebo from 2 studies (393 patients). The individual odds ratios were 0.33 and 0.49, with a summary odds ratio of 0.40 (95% CI, 0.10 to 1.51).

##### Bosentan Versus Placebo

Figure 24 shows the forest plot of the odds ratio for mortality for treatment with bosentan versus placebo from 3 studies (411 patients). The dosages of bosentan across the trials were similar (62.5 mg two times daily titrated up to 125–250 mg two times daily). The duration of treatment ranged from 16 to 32 weeks. The individual odds ratios ranged from 0.23 to 4.09, with a summary odds ratio of 0.72 (95% CI, 0.14 to 3.60). The comparative efficacy of bosentan in reducing mortality compared with placebo is inconclusive given the small number of trials, wide confidence intervals, and the observation that the confidence interval includes 1.0.

Figure 24 Forest plot of odds ratio for mortality—bosentan versus placebo

CI = confidence interval

Figure 24. Forest plot of odds ratio for mortality—bosentan versus placebo. This figure shows the forest plot of the odds ratio for mortality for treatment with bosentan versus placebo from 3 studies (411 patients). The individual odds ratios ranged from 0.23 to 4.09, with a summary odds ratio of 0.72 (95% CI, 0.14 to 3.60).

##### Epoprostenol Versus Standard Therapy

Figure 25 shows the forest plot of the odds ratio for mortality for treatment with intravenous epoprostenol versus standard therapy from three studies (215 patients). The duration of therapy ranged from 8 to 12 weeks. The individual odds ratios ranged from 0.05 to 0.77, with a summary odds ratio of 0.33 (95% CI, 0.07 to 1.50). The comparative efficacy of epoprostenol in reducing mortality compared with standard therapy is inconclusive given the small number of trials, the wide confidence intervals, and the observation that the confidence interval includes 1.0.

Figure 25 Forest plot of odds ratio for mortality—intravenous epoprostenol versus standard therapy

CI = confidence interval

Figure 25. Forest plot of odds ratio for mortality—intravenous epoprostenol versus standard therapy. This figure shows the forest plot of the odds ratio for mortality for treatment with intravenous epoprostenol versus standard therapy from three studies (215 patients). The individual odds ratios ranged from 0.05 to 0.77, with a summary odds ratio of 0.33 (95% CI, 0.07 to 1.50).

##### Iloprost Versus Placebo

Figure 26 shows the forest plot of the odds ratio for mortality for treatment with aerosolized iloprost versus placebo from two studies (266 patients). Both studies contained patient groups diagnosed with non-Class 1 PH. The duration of therapy was 12 weeks in both studies. The doses of aerosolized iloprost were between 2.5 and 5.0 micrograms delivered from six to nine times daily with dosage and schedules individualized based on a predetermined algorithm. The individual odds ratios for the two studies were 0.24 and 1.10, with a summary odds ratio of 0.43 (95% CI, 0.08 to 2.47). The comparative efficacy of iloprost in reducing mortality compared with placebo is inconclusive given the small number of trials, the wide confidence intervals, and the observation that the confidence interval includes 1.0.

Figure 26 Forest plot of odds ratio for mortality—aerosolized iloprost versus placebo

CI = confidence interval

Figure 26. Forest plot of odds ratio for mortality—aerosolized iloprost versus placebo. This figure shows the forest plot of the odds ratio for mortality for treatment with aerosolized iloprost versus placebo from two studies (266 patients). The individual odds ratios for the two studies were 0.24 and 1.10, with a summary odds ratio of 0.43 (95% CI, 0.08 to 2.47).

##### Sildenafil Versus Placebo

A single eligible study compared sildenafil with placebo.187 The SUPER study was a good-quality, 4-arm RCT that compared three dosages of sildenafil (20 mg, 40 mg, and 80 mg daily) with placebo. The 4 deaths among 277 patients reported over the course of the 3-month study were distributed relatively evenly across the 4 study arms.

##### Tadalafil Versus Placebo

A single eligible study compared tadalafil with placebo.196 The PHIRST study was a good-quality, five-arm RCT that compared four doses of tadalafil (2.5 mg, 10 mg, 20 mg, and 40 mg daily) with placebo. Fifty-three percent of patients in this study also received bosentan as background therapy; limited data were reported for this subgroup of patients which prevented including this study as a test of combination versus monotherapy209. Three deaths were reported within the first 16 weeks of treatment among the 405 patients in this study: 1 in the placebo group, 1 in the 10 mg tadalafil group; and 1 in the 20 mg tadalafil group.

##### Treprostinil Versus Placebo

Figure 27 shows the forest plot of the odds ratio for mortality for treatment with treprostinil versus placebo from two studies (513 patients). The duration of treatment was 12 weeks in both studies. The method of infusion was different between the studies (intravenous versus subcutaneous). The individual odds ratios were 0.20 and 0.91, with a summary odds ratio of 0.50 (95% CI, 0.12 to 2.12). The comparative efficacy of treprostinil in reducing mortality compared with placebo is inconclusive given the small number of trials, the wide confidence intervals, and the observation that the confidence interval includes 1.0.

Figure 27 Forest plot of odds ratio for mortality—treprostinil versus placebo

CI = confidence interval

Figure 27. Forest plot of odds ratio for mortality—treprostinil versus placebo. This figure shows the forest plot of the odds ratio for mortality for treatment with treprostinil versus placebo from two studies (513 patients). The individual odds ratios were 0.20 and 0.91, with a summary odds ratio of 0.50 (95% CI, 0.12 to 2.12).

##### Vardenafil Versus Placebo

A single eligible study compared vardenafil with placebo.200 The EVALUATION study was a good-quality, RCT that compared vardenafil 5 mg daily (later increased to 5 mg 2 times daily) with placebo. Over the course of the 3-month study period, two deaths were observed among the 20 patients in the placebo arm, compared with zero deaths among the 44 patients in the active treatment arm.

##### Mortality by Drug Class

Figure 28 shows the forest plot of the odds ratio for mortality by drug class. Incidence of death after 8 to 16 weeks of treatment was decreased by treatment with prostanoids compared with standard therapy or placebo (OR 0.52; 95% CI, 0.29 to 0.95). Similar point estimates for odds ratios were observed for endothelin antagonists (OR 0.60; CI, 0.23 to 1.59) and phosphodiesterase inhibitors (OR 0.30; CI, 0.08 to 1.11), but the confidence intervals were wide and included 1.0. There was little evidence of statistical heterogeneity among the six studies of endothelin antagonists, with a Q-value of 3.33 for 5 degrees of freedom, I^2^=0, p=0.65; among the four studies of phosphodiesterase inhibitors, with a Q-value of 3.11 for 3 degrees of freedom, I2=3%, p=0.38 or among the 8 studies of prostanoids, with a Q-value of 6.75 for 7 degrees of freedom, I^2^=0, p=0.46.

Figure 28 Forest plot of odds ratio for mortality by drug class

Aer = aerosolized; Bos = bosentan; CI = confidence interval; Epo = epoprostenol; ERA = endothelin receptor antagonist; IV = intravenous; PDE5 = phosphodiesterase type 5 inhibitor; SC = subcutaneous; Sil = sildenafil; Trep = treprostinil

Figure 28. Forest plot of odds ratio for mortality by drug class. This figure shows the forest plot of the odds ratio for mortality by drug class. Incidence of death after 8 to 16 weeks of treatment was decreased by treatment with prostanoids compared with standard therapy or placebo (OR 0.52; 95% CI, 0.29 to 0.95), but not by treatment with endothelin antagonists (OR 0.60; CI, 0.23 to 1.59) or phosphodiesterase inhibitors (OR 0.30; CI, 0.08 to 1.11).

##### Combination Therapy Versus Monotherapy

Three studies representing 566 patients evaluated mortality associated with combination therapy versus mortality associated with monotherapy. The therapies differed between studies: sildenafil plus IV epoprostenol versus IV epoprostenol plus placebo, bosentan plus IV epoprostenol versus IV epoprostenol plus placebo, and bosentan or sildenafil plus aerosolized treprostinil versus bosentan or sildenafil plus placebo. The duration of treatment ranged from 12 to 16 weeks. The individual odds ratios ranged from 0.06 to 2.80, with a summary odds ratio of 0.37 (95% CI, 0.04 to 3.32). The comparative efficacy of combination therapy in reducing mortality compared with monotherapy is inconclusive given the small number of trials, the wide confidence intervals, and the observation that the confidence interval includes 1.0.

#### 6-Minute Walk Distance (6MWD)

A total of 17 RCTs representing 2587 patients reported the effects of monotherapy or combination therapy for PAH on 6MWD at 8 to 16 weeks after initiating treatment.94,106,181,182,185,187,189,190,192–194,196–198,200 In addition, one study compared bosentan with sildenafil.156 Two studies compared bosentan with placebo.94,182 One article reporting the results of two studies compared ambrisentan with placebo.187 Two studies compared sildenafil with placebo,187,189 one study compared tadalafil with placebo,196 one study compared vardenafil with placebo,200 and three studies compared iloprost with placebo.190,192,193 Three of the 12 studies evaluated combination therapy versus monotherapy: 1 sildenafil study was conducted in patients with epoprostenol as background therapy,189 and 2 iloprost studies were conducted in patients with bosentan as background therapy.192,193 Twelve of the 17 studies were rated good quality, 4 were rated fair quality, and 1^192^ was rated poor quality.

The single small, head-to-head comparison of bosentan versus sildenafil showed no statistically significant difference in 6MWD in an intention-to-treat analysis.156 Figure 29 shows the forest plot of a meta-analysis of the 17 remaining studies. The analysis revealed a statistically significant improvement in 6MWD associated with each of the 3 drug classes. Endothelin antagonists, as a class, were associated with an improvement in 6MWD of 39.9 m (95% CI, 21.4 to 58.4) whereas phosphodiesterase inhibitors and prostanoids were associated with improvements of 38.9 m (CI, 22.0 to 55.9) and 27.9 m (CI, 10.3 to 45.4), respectively. There was moderate heterogeneity among these studies, with a Q-value of 7.68 for 5 degrees of freedom, I^2^=34.89, p=0.17 for endothelin antagonists, a Q-value of 10.09 for 3 degrees of freedom, I^2^=70.28, p=0.018 for phosphodiesterase inhibitors, and a Q-value of 11.02 for 6 degrees of freedom, I^2^=45.57, p=0.088 for prostanoids.

Figure 29 Forest plot of effects of therapy by drug class on 6MWD

CI = confidence interval; ERA = endothelin receptor antagonist; PDE5 = phosphodiesterase type 5 inhibitor

Figure 29. Forest plot of effects of therapy by drug class on 6MWD. This figure shows the forest plot of a meta-analysis of the 17 remaining studies. The analysis revealed a statistically significant improvement in 6MWD associated with each of the 3 drug classes. Endothelin antagonists, as a class, were associated with an improvement in 6MWD of 39.9 m (95% CI, 21.4 to 58.4) whereas phosphodiesterase inhibitors and prostanoids were associated with improvements of 38.9 m (CI, 22.0 to 55.9) and 27.9 m (CI, 10.3 to 45.4), respectively.

Two good-quality studies189,193 and one fair-quality study192 involving 363 patients evaluated changes in 6MWD associated with combination therapy versus monotherapy. One study evaluated the efficacy of sildenafil with epoprostenol as background therapy, and two evaluated the efficacy of iloprost with bosentan as background therapy. The summary estimate of the difference in means for these 3 studies was 23.9 (95% CI, 8.0 to 39.9). This finding suggests a moderate improvement in 6MWD associated with combination therapy compared with monotherapy.

A fourth study provides additional information about the comparison of combination therapy versus monotherapy. Barst et al.209 conducted a subgroup analysis of the PHIRST study, which was a 5-arm RCT that compared 4 doses of tadalafil with placebo. Of the 405 patients enrolled in that study, 215 (53%) were on bosentan as background therapy. The investigators authors reported mean change from baseline in 6MWD for the placebo arm and the study arm that received tadalafil 40 mg per/day at 8, 12, and 16 weeks, for both the patients on background bosentan and the patients who were treatment-naïve patients (only the 40 mg/day dose of tadalafil was reported because that was the only dose that showed significant differences in primary and secondary efficacy analyses). At the 16-week assessment, the mean change in 6MWD was 40.2 m (95% CI, 23.1 to 57.2) among patients on background therapy who received tadalafil 40 mg per day; 18.8 m (CI, 0.5 to 37.2) for patients on background therapy who received placebo; 42.2 m (CI, 26.7 to 57.5) for treatment-naïve patients on tadalafil 40 mg per day; and −2.9 m (CI, −22.8 to 17.1) for treatment-naïve patients on placebo. This corresponds to a placebo-corrected difference of 21.4 m among patients on background bosentan and 45.1 m among treatment-naïve patients. This non-randomized comparison (without testing for statistical significance testing) tentatively suggests that 6MWD improvement associated with monotherapy with 40 mg per day of tadalafil after 16 weeks of treatment may be greater than the improvement in 6MWD associated with adding tadalafil to an existing treatment regimen that includes bosentan. These limited and potentially confounded data suggest that monotherapy may have a greater effect on 6MWD relative to adding a second treatment to existing background therapy. Interpretation of these findings is further complicated by important differences between groups at baseline, including the observation that 74 percent of treatment-naïve patients had a duration of PAH of less than 2 years compared with 38 percent of patients on bosentan background therapy.

We created a funnel plot that included the 17 RCTs reported in Figure 29. Visual inspection of this funnel plot suggested an absence of publication bias. We used 6MWD to evaluate for possible publication bias because it is the outcome that was most commonly reported among the studies included in this report.

#### Hospitalization

A total of 9 RCTs representing 1918 patients reported the effects of monotherapy or combination therapy for PAH on hospitalization for worsening of PAH within 8 to 16 weeks after initiating treatment (Figure 30).106,131,182,187,189,193,196,200 One study compared bosentan with placebo,182 one article reporting the results of two studies compared ambrisentan with placebo,106 two studies compared sildenafil with placebo187,189 (one with epoprostenol as background therapy), one study compared tadalafil with placebo,196 one study compared vardenafil with placebo,200 one study compared iloprost with placebo with bosentan as background therapy193 and one study compared treprostinil with placebo.131 All nine studies were rated good quality. Meta-analysis of these studies revealed a statistically significant reduction in hospitalization associated with endothelin antagonists (OR 0.34; 95% CI, 0.17 to 0.69) and phosphodiesterase inhibitors (OR 0.48; CI, 0.25 to 0.91) while data on prostanoids were inconclusive (OR 0.42; CI, 0.06 to 3.08). There was little evidence of statistical heterogeneity among the 4 studies involving endothelin antagonists, with a Q-value of 2.34 for 3 degrees of freedom, I^2^=0, p=0.51.

Figure 30 Forest plot of effects of therapy by drug class on hospitalization

CI = confidence interval; ERA = endothelin receptor antagonist; PDE5 = phosphodiesterase type 5 inhibitor

Figure 30. Forest plot of effects of therapy by drug class on hospitalization. This figure shows the forest plot from of 9 RCTs representing 1918 patients reporting the effects of monotherapy or combination therapy for PAH on hospitalization for worsening of PAH within 8 to 16 weeks after initiating treatment. Meta-analysis of these studies revealed a statistically significant reduction in hospitalization associated with endothelin antagonists (OR 0.34; 95% CI, 0.17 to 0.69) and phosphodiesterase inhibitors (OR 0.48; CI, 0.25 to 0.91) but not with prostanoids (OR 0.42; CI, 0.06 to 3.08).

Three good-quality studies131,189,193 involving 566 patients evaluated hospital admissions due to worsening PAH symptoms associated with combination therapy versus monotherapy. One study evaluated the efficacy of sildenafil with epoprostenol as background therapy, one evaluated the efficacy of iloprost with bosentan as background therapy, and one evaluated the efficacy of treprostinil with bosentan or sildenafil as background therapy. The summary estimate of the odds ratios for these 3 studies was 0.64 (95% CI, 0.31 to 1.36). This represents insufficient evidence to conclude whether combination therapy and monotherapy differ in their effects on hospitalization incidence during the first 2 to 4 months of treatment.

#### Pulmonary Vascular Resistance

A total of 11 RCTs representing 877 patients reported the effects of monotherapy or combination therapy for PAH on PVR as assessed by right heart catheterization at 8 to 16 weeks after initiating treatment (Figure 31).85,94,181,183,185–187,190,193,194

Figure 31 Forest plot of effects of therapy by drug class on pulmonary vascular resistance

CI = confidence interval; ERA = endothelin receptor antagonist; PDE5 = phosphodiesterase type 5 inhibitor

Figure 31. Forest plot of effects of therapy by drug class on pulmonary vascular resistance. This figure shows a forest plot from 11 RCTs representing 877 patients reported the effects of monotherapy or combination therapy for PAH on PVR as assessed by right heart catheterization at 8 to 16 weeks after initiating treatment. The summary estimate for endothelin antagonists was −217.5 mm Hg/liter/min (95% CI, −424.4 to −10.7). The single study that evaluated a phosphodiesterase inhibitor (sildenafil) reported an improvement in PVR associated with active treatment of −224.7 mm Hg/liter/min (CI, −339.6 to −109.8). Meta-analysis of the five studies that evaluated a prostanoid as the active treatment demonstrated an improvement in PVR associated with active treatment of −256.2 mm Hg/liter/min (CI, −440.4 to −71.9).

Four studies compared bosentan with placebo,94,183,185 one study compared bosentan plus epoprostenol to epoprostenol plus placebo,186 one study compared iloprost with placebo,190 one study compared iloprost plus bosentan with bosentan plus placebo,193 four studies compared epoprostenol with standard therapy,85,181,194 and one study compared sildenafil with placebo.187 Eight studies were rated good quality and three fair quality.185,194

Figure 31 shows the forest plot of the 11 RCTs with meta-analysis by drug class. Meta-analysis of the five studies that evaluated an endothelin antagonist as the active treatment showed a summary estimate of −217.5 mm Hg/liter/min (95% CI, −424.4 to −10.7). Heterogeneity was very high, with a Q-value of 15.87 for 3 degrees of freedom, I^2^=74.79%, p=0.003. The single study that evaluated a phosphodiesterase inhibitor (sildenafil) reported an improvement in PVR associated with active treatment of −224.7 mm Hg/liter/min (CI, −339.6 to −109.8). Meta-analysis of the five studies that evaluated a prostanoid as the active treatment demonstrated an improvement in PVR associated with active treatment of −256.2 mm Hg/liter/min (CI, −440.4 to −71.9). Heterogeneity was very high, with a Q-value of 27.96 for 4 degrees of freedom, I^2^=85.7%, p<0.001. Only two studies compared combination therapy with monotherapy using PVR as assessed by right heart catheterization as an outcome at 8 to 16 weeks after initiating treatment. The summary estimate of the difference in means for these two studies was −33.2 (CI, −149.5 to 83.1).

#### Mean Pulmonary Artery Pressure

Thirteen RCTs representing 1559 patients reported mPAP as assessed by RHC 8 to 16 weeks after initiation of treatment.85,94,181,183,185–188,190,193,194,197 Six studies evaluated an endothelin antagonist, two studies evaluated the phosphodiesterase inhibitor sildenafil, and five studies evaluated a prostanoid. Two studies were combination therapy studies: one compared bosentan plus epoprostenol with placebo and epoprostenol,186 and one compared iloprost plus bosentan with placebo plus bosentan.193 Nine studies were rated good quality and four fair quality.

Figure 32 shows the forest plot of a meta-analysis by drug class, which revealed significant improvement in mPAP for all three drug classes. The summary change in mean arterial pressures were −3.5 mmHg (95% CI, −6.5 to −0.5) for endothelin antagonists, −3.6 mmHg (CI, −5.2 to −2.0) for phosphodiesterase inhibitors (sildenafil only), and −3.2 mmHg for prostanoids (CI, −5.6 to −0.8). There was high heterogeneity among the 6 studies of endothelin antagonists, with a Q-value of 23.3 for 5 degrees of freedom, I^2^=78.5%, p<0.001, and high heterogeneity among the 5 studies of prostanoids, with a Q-value of 13.85 for 4 degrees of freedom, I^2^=71.13%, p=0.008. Only two studies compared combination therapy with monotherapy using mPAP as an outcome at 8 to 16 weeks after initiating treatment. The summary estimate of the difference in means for these two studies was −4.1 (95% CI, −7.6 to −0.6).

Figure 32 Forest plot of effects of therapy by drug class on mean pulmonary artery pressure (mPAP)

Bos = bosentan; CI = confidence interval; Epo = epoprostenol; ERA = endothelin receptor antagonist; PDE5 = phosphodiesterase type 5 inhibitor

Figure 32. Forest plot of effects of therapy by drug class on mean pulmonary artery pressure. This figure shows a forest plot from 13 RCTs representing 1559 patients reporting mPAP as assessed by RHC 8 to 16 weeks after initiation of treatment. There was significant improvement in mPAP for all three drug classes. The summary change in mean arterial pressures were −3.5 mmHg (95% CI, −6.5 to −0.5) for endothelin antagonists, −3.6 mmHg (CI, −5.2 to −2.0) for phosphodiesterase inhibitors (sildenafil only), and −3.2 mmHg for prostanoids (CI, −5.6 to −0.8).

#### Cardiac Index

A total of 6 RCTs representing 982 patients reported cardiac index assessed 8 to 16 weeks after initiation of treatment compared with placebo or standard therapy (Figure 33).85,94,156,187,194,197 One good-quality study compared bosentan with placebo,94 one good-quality study compared bosentan plus epoprostenol with epoprostenol plus placebo,186 one good-quality and one fair-quality study compared epoprostenol with standard therapy,85,194 one good-quality study compared three doses of sildenafil with each other and with placebo,187 and one good quality study compared subcutaneous treprostinil with placebo.197 An additional good-quality study was a head-to-head trial that compared bosentan with sildenafil.156

Figure 33 Forest plot of effects of therapy by drug class on cardiac index

CI = confidence interval; Epo = epoprostenol; ERA = endothelin receptor antagonist; PDE5 = phosphodiesterase type 5 inhibitor

Figure 33. Forest plot of effects of therapy by drug class on cardiac index. This figure shows a forest plot from 6 RCTs representing 982 patients reporting cardiac index assessed 8 to 16 weeks after initiation of treatment compared with placebo or standard therapy. The single RCT that compared bosentan with placebo demonstrated a significant improvement in cardiac index of 1.0 L per minute per meter-squared (95% CI, 0.6 to 1.4) at 12 weeks, in favor of bosentan. The single study that compared sildenafil with placebo permitted dose comparisons; each of the 3 doses (20, 40, and 80 mg three times daily) was associated with statistically significant improvement in cardiac index. Combining the data from all three sildenafil doses generated a summary estimate of an improvement in cardiac index associated with sildenafil versus placebo at 12 weeks of 0.3 L per minute per meter-squared (CI, 0.1 to 0.5). Meta-analysis of the three studies that evaluated a prostanoid generated a summary estimate for improvement in cardiac index of 0.4 L per minute per meter-squared (CI, 0.1 to 0.7) at 12 weeks.

The single RCT that compared bosentan with placebo demonstrated a significant improvement in cardiac index of 1.0 L per minute per meter-squared (95% CI, 0.6 to 1.4) at 12 weeks, in favor of bosentan. The single study that compared sildenafil with placebo permitted dose comparisons; each of the 3 doses (20, 40, and 80 mg three times daily) was associated with statistically significant improvement in cardiac index. Combining the data from all three sildenafil doses generated a summary estimate of an improvement in cardiac index associated with sildenafil versus placebo at 12 weeks of 0.3 L per minute per meter-squared (CI, 0.1 to 0.5). Meta-analysis of the three studies that evaluated a prostanoid generated a summary estimate for improvement in cardiac index of 0.4 L per minute per meter-squared (CI, 0.1 to 0.7) at 12 weeks.

#### Adverse Events

Adverse events that occurred during the first 8 to 16 weeks after initiation of treatment were reported in 21 of the 28 RCTs that compared an endothelin antagonist, phosphodiesterase inhibitor, or prostanoid with either placebo or standard therapy. Adverse events were not reported in the single RCT that compared two active therapies.156 The most commonly assessed and reported adverse events were headache, dizziness, diarrhea, peripheral edema, jaw pain, flushing, and cough.

For these studies, we computed a summary estimate for the odds ratio for each of three classes of drugs: (1) endothelin antagonists, (2) phosphodiesterase inhibitors, and (3) prostanoids. We computed separate summary estimates for the odds ratio of all prostanoids versus prostanoids delivered via an aerosolized route of administration. An odds ratio greater than 1.0 indicates a higher incidence of adverse events associated with active treatment, and an odds ratio less than 1.0 indicates a lower incidence of adverse events associated with active treatment. When combination therapy was compared with monotherapy, an odds ratio greater than 1.0 indicates a higher incidence of adverse events associated with monotherapy.

##### Headache

A total of 16 RCTs representing 2899 patients assessed the incidence of headache within the first 8 to 16 weeks of initiating therapy (Figure 34).94,106,131,182,183,186–190,193,196,197,199,200 Fourteen studies were rated good quality and two fair quality. There was moderate heterogeneity among these studies, with a Q-value of 36.3 for 14 degrees of freedom, I^2^=61.4%, p<0.001. Meta-analysis of 6 good-quality studies of endothelin antagonists involving 780 patients yielded a summary odds ratio of 1.16 (95% CI, 0.77 to 1.77). There was a two-fold higher incidence of headache among patients treated with phosphodiesterase inhibitors compared with placebo or standard therapy (OR 1.98; CI, 1.18 to 3.32). The 95-percent confidence interval for the summary odds ratio associated with all prostanoids includes 1.0 (CI, 0.93 to 4.53), but there was a significantly higher incidence of headache among patients treated with aerosolized prostanoids (OR 2.35; CI, 1.50 to 3.70).

Figure 34 Forest plot of effects of therapy by drug class on headache

CI = confidence interval; ERA = endothelin receptor antagonist; PDE5 = phosphodiesterase type 5 inhibitor

Figure 34. Forest plot of effects of therapy by drug class on headache. This figure shows a forest plot from 16 RCTs representing 2899 patients assessed the incidence of headache within the first 8 to 16 weeks of initiating therapy. Meta-analysis of 6 studies of endothelin antagonists involving 780 patients yielded a summary odds ratio of 1.16 (95% CI, 0.77 to 1.77). There was a two-fold higher incidence of headache among patients treated with phosphodiesterase inhibitors compared with placebo or standard therapy (OR 1.98; CI, 1.18 to 3.32). The 95-percent confidence interval for the summary odds ratio associated with all prostanoids includes 2.05 (CI, 0.93 to 4.53), but there was a significantly higher incidence of headache among patients treated with aerosolized prostanoids (OR 2.35; CI, 1.50 to 3.70).

There was little evidence of statistical heterogeneity among the 6 studies of endothelin antagonists, with a Q-value of 4.7 for 5 degrees of freedom, I^2^=0, p<0.45 and high heterogeneity among both the 4 studies of phosphodiesterase inhibitors, with a Q-value of 10.13 for 4 degrees of freedom, I^2^=60.51%, p<0.038, and the 4 studies of prostanoids, with a Q-value of 25.68 for 4 degrees of freedom, I^2^=84.42%, p<0.001.

Three good-quality studies186,189,193 involving 356 patients evaluated the incidence of headache associated with combination therapy versus monotherapy. One study evaluated the efficacy of bosentan with epoprostenol as background therapy, one compared sildenafil with placebo with epoprostenol as background therapy, and one evaluated the efficacy of iloprost with bosentan as background therapy. We did not estimate a summary estimate for the odds ratio for headache associated with combination therapy compared with monotherapy because of the high degree of heterogeneity between studies, including the use of different drugs for both active and background therapy.

##### Dizziness

A total of 11 RCTs representing 1872 patients assessed the incidence of dizziness within the first 8 to 16 weeks of initiating therapy (Figure 35).131,182,183,186,188–190,193,197,199,200 Nine studies were rated good quality and two fair quality. With the exception of one small study186 that reported a higher incidence of dizziness in the in the epoprostenol plus bosentan study arm compared with the epoprostenol plus placebo arm, there were no statistically significant differences in the proportion of patients reporting adverse events between active and control groups across in any of the individual studies, or within drug class. Meta-analysis of 3 good-quality studies of endothelin antagonists involving 300 patients yielded a summary odds ratio of 0.45 (95% CI, 0.24 to 0.85). There was no apparent association between treatment of phosphodiesterase inhibitors (OR 1.04; CI, 0.60 to 1.81) or prostanoids (OR 0.97; CI, 0.66 to 1.44) and incidence of dizziness. There was little evidence of statistical heterogeneity among the 5 studies of prostanoids, with a Q-value of 2.26 for degrees of freedom, I^2^=0, p=0.85.

Figure 35 Forest plot of effects of therapy by drug class on dizziness

CI = confidence interval; ERA = endothelin receptor antagonist; PDE5 = phosphodiesterase type 5 inhibitor

Figure 35. Forest plot of effects of therapy by drug class on dizziness. This figure shows a forest plot from 11 RCTs representing 1872 patients assessed the incidence of dizziness within the first 8 to 16 weeks of initiating therapy. Meta-analysis of 3 studies of endothelin antagonists involving 300 patients yielded a summary odds ratio of 0.45 (95% CI, 0.24 to 0.85). There was no apparent association between treatment of phosphodiesterase inhibitors (OR 1.04; CI, 0.60 to 1.81) or prostanoids (OR 0.97; CI, 0.66 to 1.44) and incidence of dizziness.

Three good-quality studies186,189,193 involving 356 patients evaluated the incidence of dizziness associated with combination therapy versus monotherapy. One study evaluated the efficacy of bosentan with epoprostenol as background therapy, one compared sildenafil with placebo with epoprostenol as background therapy, and one evaluated the efficacy of iloprost with bosentan as background therapy. We did not estimate a summary estimate for the odds ratio for dizziness associated with combination therapy compared with monotherapy because of the high degree of clinical heterogeneity between studies, including the use of different drugs for both active and background therapy.

##### Diarrhea

A total of 11 RCTs representing 2331 patients assessed the incidence of diarrhea within the first 8 to 16 weeks of initiating therapy (Figure 36).131,186–190,194,196,197,199,200 Eight studies were rated good quality and three fair quality. Meta-analysis of these studies revealed no statistically significant differences in the proportion of patients reporting adverse events between active and control groups within any of the three drug class (OR 3.20; 95% CI, 0.67 to 15.38 for endothelin antagonists; OR 1.25; CI, 0.84 to 1.88 for phosphodiesterase inhibitors; and OR 1.77; CI, 0.57 to 5.53 for prostanoids). There was little evidence of statistical heterogeneity among the five studies of phosphodiesterase inhibitors, with a Q-value of 1.39 for 4 degrees of freedom, I^2^=0, p<0.85, and high heterogeneity among the five studies of prostanoids, with a Q-value of 27.89 for 4 degrees of freedom, I^2^=85.66%, p<0.001.

Figure 36 Forest plot of effects of therapy by drug class on diarrhea

CI = confidence interval; ERA = endothelin receptor antagonist; PDE5 = phosphodiesterase type 5 inhibitor

Figure 36. Forest plot of effects of therapy by drug class on diarrhea. This figure shows a forest plot from 11 RCTs representing 2331 patients assessed the incidence of diarrhea within the first 8 to 16 weeks of initiating therapy. Meta-analysis of these studies revealed no statistically significant differences in the proportion of patients reporting adverse events between active and control groups within any of the three drug class (OR 3.20; 95% CI, 0.67 to 15.38 for endothelin antagonists; OR 1.25; CI, 0.84 to 1.88 for phosphodiesterase inhibitors; and OR 1.77; CI, 0.57 to 5.53 for prostanoids).

Two good-quality studies186,189 involving 289 patients evaluated the incidence of diarrhea associated with combination therapy versus monotherapy. One study evaluated the efficacy of bosentan with epoprostenol as background therapy, one compared sildenafil with placebo with epoprostenol as background therapy, and one evaluated the efficacy of tadalafil with bosentan as background therapy. We did not estimate a summary estimate for the odds ratio for diarrhea associated with combination therapy compared with monotherapy because of the high degree of heterogeneity between studies, including the use of different drugs for both active and background therapy.

##### Peripheral Edema

A total of 9 RCTs representing 1880 patients assessed the incidence of peripheral edema within the first 8 to 16 weeks of initiating therapy (Figure 37).106,183,186,189,190,193,196,197 All nine studies were rated good quality. Meta-analysis by drug class yielded statistically significantly increased odds ratios for phosphodiesterase inhibitors (OR 3.32; 95% CI, 1.40 to 7.87), but the results for endothelin antagonists (OR 1.93; CI, 0.64 to 5.85) and prostanoids (OR 1.85; CI, 0.81 to 4.21) were inconclusive. This finding, however, does not necessarily indicate that phosphodiesterase inhibitors are associated with a higher incidence of peripheral edema relative to endothelin receptor antagonists or prostanoids. There was moderate heterogeneity among the 4 studies of endothelin antagonists, with a Q-value of 7.33 for 3 degrees of freedom, I^2^=59.07%, p=0.062.

Figure 37 Forest plot of effects of therapy by drug class on peripheral edema

CI = confidence interval; ERA = endothelin receptor antagonist; PDE5 = phosphodiesterase type 5 inhibitor

Figure 37. Forest plot of effects of therapy by drug class on peripheral edema. This figure shows a forest plot from 9 RCTs representing 1880 patients assessed the incidence of peripheral edema within the first 8 to 16 weeks of initiating therapy. Meta-analysis by drug class yielded statistically significantly increased odds ratios for phosphodiesterase inhibitors (OR 3.32; 95% CI, 1.40 to 7.87) but not for endothelin antagonists (OR 1.93; CI, 0.64 to 5.85) or prostanoids (OR 1.85; CI, 0.81 to 4.21). This finding, however, does not necessarily indicate that phosphodiesterase inhibitors are associated with a higher incidence of peripheral edema relative to endothelin receptor antagonists or prostanoids.

Three good-quality studies186,189,193 involving 356 patients evaluated the incidence of peripheral edema associated with combination therapy versus monotherapy. One study evaluated the efficacy of bosentan with epoprostenol as background therapy, one compared sildenafil with placebo with epoprostenol as background therapy, and one evaluated the efficacy of iloprost with bosentan as background therapy. We did not calculate a summary estimate for the odds ratio for peripheral edema associated with combination therapy compared with monotherapy because of the high degree of heterogeneity between studies, including the use of different drugs for both active and background therapy.

##### Jaw Pain

A total of 7 RCTs assessed the incidence of jaw pain within the first 8 to 16 weeks of initiating therapy (Figure 38).186,189,190,193,194,197,199 Five studies were rated good quality and two fair quality. Of these, 5 RCTs representing 894 patients compared intravenous, subcutaneous, or aerosolized prostanoids with placebo or standard therapy. Meta-analysis of these 5 studies yielded a summary estimate of the odds ratio of 6.68 (95% CI, 2.28 to 19.62). There was moderate heterogeneity among these 5 studies, with a Q-value of 10.01 for 4 degrees of freedom, I^2^=60.04%, p=0.04. Aerosolized prostanoids were also associated with a significantly increased risk of jaw pain (OR 4.32; CI, 1.67 to 11.17).

Figure 38 Forest plot of effects of therapy by drug class on jaw pain

CI = confidence interval; ERA = endothelin receptor antagonist; PDE5 = phosphodiesterase type 5 inhibitor

Figure 38. Forest plot of effects of therapy by drug class on jaw pain. This figure shows a forest plot from 7 RCTs compared intravenous, subcutaneous, or aerosolized prostanoids with placebo or standard therapy. The single study that compared an endothelin antagonist (bosentan) to placebo yielded an odds ratio of 0.14 (95% CI, 0.02 to 1.34). The single study that compared a phosphodiesterase inhibitor (sildenafil) to placebo yielded an odds ratio of 1.18 (CI, 0.51 to 2.70). Meta-analysis yielded a summary estimate of the odds ratio of 6.68 (CI, 2.28 to 19.62). Aerosolized prostanoids were also associated with a significantly increased risk of jaw pain (OR 4.32; CI, 1.67 to 11.17).

Three good-quality studies186,189,193 involving 356 patients evaluated the incidence of jaw pain associated with combination therapy versus monotherapy. One study evaluated the efficacy of bosentan with epoprostenol as background therapy, one compared sildenafil with placebo with epoprostenol as background therapy, and one evaluated the efficacy of iloprost with bosentan as background therapy. We did not calculate a summary estimate for the odds ratio for jaw pain associated with combination therapy compared with monotherapy because of the high degree of clinical heterogeneity between studies, including the use of different drugs for both active and background therapy.

##### Flushing

A total of 10 RCTs representing 2113 patients assessed the incidence of flushing within the first 8 to 16 weeks of initiating therapy (Figure 39).106,131,182,187,189,190,193,196,200 All 10 studies were rated good quality. Meta-analysis of these studies suggest an approximately two-fold increase in the risk of flushing associated with both endothelin antagonists (OR 2.63; 95% CI, 0.94 to 7.40) and phosphodiesterase inhibitors (OR 2.46; CI, 1.27 to 4.75), but the 95-percent confidence interval of the summary estimate for endothelin antagonists includes 1.0. The risk of flushing was also elevated with aerosolized prostanoids (OR 4.72; CI, 2.13 to 10.42). There was moderate heterogeneity among the 4 studies of phosphodiesterase inhibitors, with a Q-value of 4.05 for 3 degrees of freedom, I^2^=25.9%, p=0.26.

Figure 39 Forest plot of effects of therapy by drug class on flushing

CI = confidence interval; ERA = endothelin receptor antagonist; PDE5 = phosphodiesterase type 5 inhibitor

Figure 39. Forest plot of effects of therapy by drug class on flushing. This figure shows a forest plot from 10 RCTs representing 2113 patients assessed the incidence of flushing within the first 8 to 16 weeks of initiating therapy. Meta-analysis of these studies suggest an approximately two-fold increase in the risk of flushing associated with both endothelin antagonists (OR 2.63; 95% CI, 0.94 to 7.40) and phosphodiesterase inhibitors (OR 2.46; CI, 1.27 to 4.75), but the 95-percent confidence interval of the summary estimate for endothelin antagonists includes 1.0. The risk of jaw pain was also elevated with aerosolized prostanoids (OR 4.72; CI, 2.13 to 10.42).

Two good-quality studies189,193 involving 323 patients evaluated the incidence of flushing associated with combination therapy versus monotherapy. One study compared sildenafil with placebo with epoprostenol as background therapy and one compared iloprost with placebo with bosentan as background therapy. We did not estimate a summary estimate for the odds ratio for flushing associated with combination therapy compared with monotherapy because of the high degree of clinical heterogeneity between studies, including the use of different drugs for both active and background therapy.

##### Cough

A total of 8 RCTs representing 1306 patients assessed the incidence of cough within the first 8 to 16 weeks of initiating therapy (Figure 40).131,182,186–188,190,193,199 Six studies were rated good quality and two fair quality. There was moderate heterogeneity among the 8 studies, with a Q-value of 12.6 for 7 degrees of freedom, I^2^=44%, p=0.08. Meta-analysis of these studies revealed no statistically significant differences in the proportion of patients reporting adverse events between active and control groups for endothelin antagonists and phosphodiesterase inhibitors.

Figure 40 Forest plot of effects of therapy by drug class on cough

CI = confidence interval; ERA = endothelin receptor antagonist; PDE5 = phosphodiesterase type 5 inhibitor

Figure 40. Forest plot of effects of therapy by drug class on cough. This figure shows a forest plot from 8 RCTs representing 1306 patients assessed the incidence of cough within the first 8 to 16 weeks of initiating therapy. Meta-analysis of these studies revealed no statistically significant differences in the proportion of patients reporting adverse events between active and control groups for endothelin antagonists and phosphodiesterase inhibitors (OR 0.50; CI, 0.19 to 1.30 and OR 1.07; 0.45 to 2.57 respectively). Prostanoids, however, are associated with a higher incidence of cough compared with placebo or standard therapy. The summary estimate of the odds ratio for cough associated with all prostanoids (aerosolized or intravenous) is 2.34 (95% CI, 1.62 to 3.37). Among the 3 studies that used an aerosolized route of administration for prostanoids, the summary estimate of the odds ratio for cough was 2.42 (CI, 1.66 to 3.53).

Prostanoids, however, are associated with a higher incidence of cough compared with placebo or standard therapy. The summary estimate of the odds ratio for cough associated with all prostanoids (aerosolized or intravenous) is 2.34 (95% CI, 1.62 to 3.37). There was little evidence of statistical heterogeneity among these 4 studies, with a Q-value of 1.93 for 3 degrees of freedom, I^2^=0, p=0.59. Among the 3 studies that used an aerosolized route of administration for prostanoids, the summary estimate of the odds ratio for cough was 2.42 (CI, 1.66 to 3.53). Two good-quality studies186,193 involving 100 patients evaluated the incidence of cough associated with combination therapy versus monotherapy. One study evaluated the efficacy of bosentan with epoprostenol as background therapy, and one evaluated the efficacy of iloprost with bosentan as background therapy. We did not estimate a summary estimate for the odds ratio for cough associated with combination therapy compared with monotherapy because of the high degree of heterogeneity between studies, including the use of different drugs for both active and background therapy.

##### Infections

A total of 8 RCTs representing 1210 patients assessed the incidence of infections within the first 8 to 16 weeks of initiating therapy (Figure 41).186,188,189,192–194,196,200 Five studies were rated good quality and three fair quality. There was low heterogeneity among these studies, with a Q-value of 8.0 for 7 degrees of freedom, I^2^=12.8%, p=0.33. The single study that compared an endothelin antagonist (bosentan) with placebo with epoprostenol as background therapy did not demonstrate an association between treatment and incidence of infection (OR 0.45; 95% CI, 0.05 to 3.72). Meta-analysis of 4 studies demonstrated an increase in incidence of infections associated with phosphodiesterase inhibitors (OR 2.17; CI, 1.20 to 3.94). There was little evidence of statistical heterogeneity among these 4 studies, with a Q-value of 3.94 for 3 degrees of freedom, I^2^=0, p=0.73. Meta-analysis of 3 studies did not demonstrate an association between prostanoid treatment and incidence of infection (OR 1.12; CI, 0.13 to 9.87).

Figure 41 Forest plot of effects of therapy by drug class on infections

CI = confidence interval; ERA = endothelin receptor antagonist; PDE5 = phosphodiesterase type 5 inhibitor

Figure 41. Forest plot of effects of therapy by drug class on infections. This figure shows a forest plot from 8 RCTs representing 1210 patients assessed the incidence of infections within the first 8 to 16 weeks of initiating therapy. The single study that compared an endothelin antagonist (bosentan) to placebo with epoprostenol as background therapy did not demonstrate an association between treatment and incidence of infection (OR 0.45; 95% CI, 0.05 to 3.72). Meta-analysis of 4 studies demonstrated an increase in incidence of infections associated with phosphodiesterase inhibitors (OR 2.17; CI, 1.20 to 3.94). Meta-analysis of 3 studies did not demonstrate an association between prostanoid treatment and incidence of infection (OR 1.12; CI, 0.13 to 9.87).

Three good-quality studies186,189,193 and one fair-quality study192 involving 396 patients evaluated the incidence of infections associated with combination therapy versus monotherapy. We did not calculate a summary estimate for the odds ratio for infections associated with combination therapy compared with monotherapy because of the high degree of heterogeneity between studies, including the use of different drugs for both active and background therapy.

### Summary Strength of Evidence for KQ 3

Results for these outcomes and comparisons, along with ratings for strength of evidence (SOE) are shown in Tables 25–31.

Table 25 Summary strength of evidence for KQ 3: Mortality

Comparison | Number of Studies (Patients) | Domains | | | | Strength of Evidence Effect Estimate (95% CI)
Comparison | Number of Studies (Patients) | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Effect Estimate (95% CI)
Ambrisentan vs. placebo | 2 (393) | Low (2) | Consistent | Direct | Imprecise | SOE = Insufficient OR 0.40 (0.10 to 1.51) Inconclusive benefit (few studies, few deaths lead to wide CI)
Bosentan vs. placebo | 3 (411) | Low (2) Moderate (1) | Inconsistent | Direct | Imprecise | SOE = Insufficient OR 0.72 (0.14 to 3.60) Inconclusive benefit (few studies, few deaths lead to wide CI)
Epoprostenol vs. placebo or standard therapy | 3 (215) | Low (2) Moderate (1) | Inconsistent | Direct | Imprecise | SOE = Insufficient OR 0.33 (0.07 to 1.50) Inconclusive benefit (few studies, few deaths lead to wide CI)
Iloprost vs. placebo | 2 (266) | Low (1) Moderate (1) | Inconsistent | Direct | Imprecise | SOE = Insufficient OR 0.43 (0.08 to 2.47) Inconclusive benefit (few studies, few deaths lead to wide CI)
Sildenafil vs. placebo | 1 (277) | Low (1) | NA | Direct | Imprecise | SOE = Insufficient OR 1.01 (0.10 to 9.92) Inconclusive benefit (single study, wide CI)
Tadalafil vs. placebo | 1 (405) | Low (1) | NA | Direct | Imprecise | SOE = Insufficient OR 0.50 (0.05 to 5.63) Inconclusive benefit (single study, wide CI)
Treprostinil vs. placebo | 2 (513) | Low (1) Moderate (1) | Consistent | Direct | Imprecise | SOE = Insufficient OR 0.50 (0.12 to 2.12) Inconclusive benefit (few studies, few deaths lead to wide CI)
Vardenafil vs. placebo | 1 (64) | Low (1) | NA | Direct | Imprecise | SOE = Insufficient OR 0.08 (0.00 to 1.82) Inconclusive benefit (single study, wide CI)
Endothelin antagonists vs. placebo | 6 (838) | Low (5) Moderate (1) | Inconsistent | Direct | Imprecise | SOE = Insufficient OR 0.60 (0.23 to 1.59) Inconclusive benefit (few studies, few deaths lead to wide CI)
Phosphodiesterase inhibitors vs. placebo | 4 (1011) | Low (4) | Inconsistent | Direct | Imprecise | SOE = Insufficient OR 0.30 (0.08 to 1.11) Inconclusive benefit (few studies, few deaths lead to wide CI)
Prostanoids vs. placebo or standard therapy | 8 (1229) | Low (5) Moderate (3) | Inconsistent | Direct | Precise | SOE = Low OR 0.52 (0.29 to 0.95) Favors prostanoids
Combination therapy vs. monotherapy | 3 (566) | Low (3) | Inconsistent | Indirect | Imprecise | SOE = Insufficient OR 0.37 (0.04 to 3.32) Inconclusive benefit (few studies, few deaths lead to wide CI)

CI = confidence interval; NA = not applicable; OR = odds ratio; SOE = strength of evidence

Note: No eligible studies compared tadalafil or vardenafil monotherapy with either placebo or standard therapy.

Table 26 Summary strength of evidence for KQ 3: 6MWD

Comparison | Number of Studies (Patients) | Domains | | | | Strength of Evidence Effect Estimate (95% CI)
Comparison | Number of Studies (Patients) | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Effect Estimate (95% CI)
Endothelin antagonists vs. placebo | 6 (663) | Low (4) Moderate (2) | Consistent | Direct | Imprecise | SOE = Moderate Mean difference 39.9 (21.4 to 58.4) Favors endothelin antagonists
Phosphodiesterase inhibitors vs. placebo | 4 (991) | Low (4) | Consistent | Direct | Imprecise | SOE = Moderate Mean difference 38.9 (22.0 to 55.9) Favors PDE inhibitors
Prostanoids vs. placebo or standard therapy | 7 (933) | Low (4) Moderate (2) High (1) | Consistent | Direct | Imprecise | SOE = Moderate Mean difference 27.9 (10.3 to 45.4) Favors prostanoids
Combination therapy vs. monotherapy | 3 (363) | Low (2) Moderate (1) | Consistent | Indirect | Imprecise | SOE = Low Mean difference 23.9 (8.0 to 39.9) Favors combination therapy

CI = confidence interval; OR = odds ratio; SOE = strength of evidence

Table 27 Summary strength of evidence for KQ 3: Hospitalization

Comparison | Number of Studies (Patients) | Domains | | | | Strength of Evidence Effect Estimate (95% CI)
Comparison | Number of Studies (Patients) | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Effect Estimate (95% CI)
Endothelin antagonists vs. placebo | 3 (606) | Low (3) | Consistent | Direct | Precise | SOE = Moderate OR 0.34 (0.17 to 0.69) Favors endothelin antagonists
Phosphodiesterase inhibitors vs. placebo | 4 (1011) | Low (4) | Consistent | Direct | Precise | SOE = Moderate OR 0.48 (0.25 to 0.91) Favors PDE inhibitors
Prostanoids vs. placebo or standard therapy | 2 (301) | Low (2) | Inconsistent | Direct | Imprecise | SOE = Insufficient OR 0.42 (0.06 to 3.08) Inconclusive benefit (few studies, wide CI)
Combination therapy vs. monotherapy | 3 (566) | Low (3) | Inconsistent | Indirect | Imprecise | SOE = Insufficient OR 0.64 (0.31 to 1.36) Inconclusive benefit (few studies, wide CI)

CI = confidence interval; OR = odds ratio; SOE = strength of evidence

Table 28 Summary strength of evidence for KQ 3: Pulmonary vascular resistance

Comparison | Number of Studies (Patients) | Domains | | | | Strength of Evidence Effect Estimate (95% CI)
Comparison | Number of Studies (Patients) | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Effect Estimate (95% CI)
Endothelin antagonists vs. placebo | 5 (139) | Low (3) Moderate (2) | Inconsistent | Indirect | Precise | SOE = Low Mean difference −217.5 (−424.4 to −10.7) Favors endothelin antagonists
Phosphodiesterase inhibitors vs. placebo | 1 (263) | Low (1) | NA | Indirect | Precise | SOE = Low Mean difference −224.7 (−339.6 to −109.8) Favors PDE inhibitors
Prostanoids vs. placebo or standard therapy | 5 (475) | Low (4) Moderate (1) | Consistent | Indirect | Precise | SOE = Low Mean difference −256.2 (−440.4 to −71.9) Favors prostanoids
Combination therapy vs. monotherapy | 2 (90) | Low (2) | Inconsistent | Indirect | Imprecise | SOE = Insufficient Mean difference −33.2 (−149.5 to 83.1) Inconclusive benefit (few studies, wide CI)

CI = confidence interval; NA = not applicable; OR = odds ratio; SOE = strength of evidence

Table 29 Summary strength of evidence for KQ 3: Mean pulmonary artery pressure

Comparison | Number of Studies (Patients) | Domains | | | | Strength of Evidence Effect Estimate (95% CI)
Comparison | Number of Studies (Patients) | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Effect Estimate (95% CI)
Endothelin antagonists vs. placebo | 6 (219) | Low (4) Moderate (2) | Consistent | Indirect | Precise | SOE = Low Mean difference −3.5 (−6.5 to −0.5) Favors endothelin antagonists
Phosphodiesterase inhibitors vs. placebo | 2 (481) | Low (1) Moderate (1) | Consistent | Indirect | Precise | SOE = Low Mean difference −3.6 (−5.2 to −2.0) Favors PDE inhibitors
Prostanoids vs. placebo or standard therapy | 5 (859) | Low (4) Moderate (1) | Consistent | Indirect | Precise | SOE = Low Mean difference −3.2 (−5.6 to −0.8) Favors prostanoids
Combination therapy vs. monotherapy | 2 (90) | Low (2) | Inconsistent | Indirect | Precise | SOE = Low Mean difference −4.1 (−7.6 to −0.6) Favors combination therapy

CI=confidence interval; OR=odds ratio; SOE=strength of evidence

Table 30 Summary strength of evidence for KQ 3: Cardiac index

Comparison | Number of Studies (Patients) | Domains | | | | Strength of Evidence Effect Estimate (95% CI)
Comparison | Number of Studies (Patients) | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Effect Estimate (95% CI)
Endothelin antagonists vs. placebo | 2 (63) | Low (2) | Inconsistent | Indirect | Imprecise | SOE = Insufficient Mean difference 0.6 (−0.2 to 1.4) Inconclusive benefit (few studies, wide CI)
Phosphodiesterase inhibitors vs. placebo | 1 (258) | Low (1) | NA | Indirect | Precise | SOE = Low Mean difference 0.3 (0.1 to 0.5) Favors PDE inhibitors
Prostanoids vs. placebo or standard therapy | 3 (661) | Low (2) Moderate (1) | Consistent | Indirect | Precise | SOE = Low Mean difference 0.4 (0.1 to 0.7)
Combination therapy vs. monotherapy | 1 (33) | Low (1) | NA | Indirect | Imprecise | SOE = Insufficient Mean difference 0.2 (−0.4 to 0.8) Inconclusive benefit (single study, wide CI)

CI = confidence interval; NA = not applicable; OR = odds ratio; SOE = strength of evidence

Table 31 Summary strength of evidence for KQ 3: Adverse events^a^

Comparison | Number of Studies (Patients) | Domains | | | | Strength of Evidence Effect Estimate (95% CI)
Comparison | Number of Studies (Patients) | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence Effect Estimate (95% CI)
Endothelin antagonists vs. placebo: Dizziness | 3 (300) | Low (3) | Consistent | Direct | Precise | SOE = Low OR 0.45 (0.24 to 0.85)
Phosphodiesterase inhibitors vs. placebo: Peripheral edema | 2 (661) | Low (2) | Consistent | Direct | Precise | SOE = Moderate OR 3.32 (1.40 to 7.87)
Phosphodiesterase inhibitors vs. placebo: Infections | 4 (959) | Low (3) Moderate (1) | Inconsistent | Direct | Precise | SOE = Low OR 2.17 (1.20 to 3.94)
Phosphodiesterase inhibitors vs. placebo: Headache | 5 (1156) | Low (4) Moderate (1) | Consistent | Direct | Precise | SOE = High OR 1.98 (1.18 to 3.32) Favors placebo
Phosphodiesterase inhibitors vs. placebo: Flushing | 4 (1002) | Low (4) | Consistent | Direct | Precise | SOE = Moderate OR 2.46 (1.27 to 4.75) Favors placebo
Prostanoids (aerosolized) vs. placebo: Headache | 3 (505) | Low (3) | Consistent | Direct | Precise | SOE = High OR 2.35 (1.50 to 3.70)
Prostanoids (aerosolized) vs. placebo: Jaw pain | 2 (270) | Low (2) | Consistent | Direct | Precise | SOE = High OR 4.32 (1.67 to 11.17) Favors placebo
Prostanoids (aerosolized) vs. placebo or standard therapy: Flushing | 3 (505) | Low (3) | Consistent | Direct | Precise | SOE = Moderate OR 4.72 (2.13 to 10.42) Favors placebo
Prostanoids (aerosolized) vs. placebo: Cough | 3 (505) | Low (3) | Consistent | Direct | Precise | SOE = High OR 2.42 (1.66 to 3.53) Favors placebo

CI = confidence interval; OR = odds ratio; SOE = strength of evidence

a Only meta-analyses that generated a summary estimate with 95% confidence intervals that did not cross 1.0 or were too imprecise to conclude no difference between groups are included in this table.