# Methods

The methods for this comparative effectiveness review follow those suggested in the AHRQ “Methods Guide for Effectiveness and Comparative Effectiveness Reviews” (available at www.effectivehealthcare.ahrq.gov/methodsguide.cfm; hereafter referred to as the Methods Guide).20 The main sections in this chapter reflect the elements of the protocol established for the systematic review; certain methods map to the PRISMA checklist.21 All methods and analyses were determined a priori.

## Topic Refinement and Review Protocol

During the topic refinement stage, we solicited input from Key Informants representing clinicians (pulmonology, cardiology, pathology), patients, scientific experts, and Federal agencies, to help define the Key Questions. The Key Questions were then posted for public comment for 30 days, and the comments received were considered in the development of the research protocol. We next convened a Technical Expert Panel (TEP), comprising clinical, content, and methodological experts, to provide input in defining populations, interventions, comparisons, or outcomes as well as identifying particular studies or databases to search. The Key Informants and members of the TEP were required to disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Any potential conflicts of interest were balanced or mitigated. Neither Key Informants nor members of the TEP did analysis of any kind and did not contribute to the writing of the report. Members of the TEP were invited to provide feedback on an initial draft of the review protocol, which was then refined based on their input, reviewed by AHRQ, and posted for public access at the AHRQ Effective Health Care Web site.22

## Literature Search Strategy

### Sources Searched

Our search strategy used the National Library of Medicine’s medical subject headings (MeSH) keyword nomenclature developed for MEDLINE^®^ and adapted for use in other databases. In consultation with our research librarians, we searched PubMed^®^, Embase^®^, and the Cochrane Database of Systematic Reviews (Appendix A). We limited the search to English-language studies conducted from 1995 to the present for KQs 1 and 2, and 1990 to the present for KQ 3; prior to 1990, newer drug treatments were not available, and prior to 1995 older echocardiographic and biomarker testing technology is less applicable. Where possible, we used existing validated search filters (such as the Clinical Queries Filters in PubMed^®^). We supplemented the electronic searches with a manual search of citations from a set of key primary and review articles. The reference list for identified pivotal articles was hand-searched and cross-referenced against our library, and additional manuscripts were retrieved. All citations were imported into an electronic database (EndNote^®^ X4; Thomson Reuters, Philadelphia, PA).

We also searched the gray literature of study registries and conference abstracts for relevant articles from completed studies. Gray literature databases included ClinicalTrials.gov; metaRegister of Controlled Trials; ClinicalStudyResults.org; WHO: International Clinical Trials Registry Platform Search Portal; and ProQuest COS Conference Papers Index. Scientific information packets were requested from the manufacturers of medications and devices and reviewed for relevant articles from completed studies not previously identified in the literature searches.

Although this was not an exhaustive strategy, the search of ClinicalTrials.gov was also used as a mechanism to ascertain publication bias by identifying completed but unpublished studies. During peer and public review of the draft report, we updated all database searches and included any eligible studies identified either through that search or through suggestions from peer and public reviewers.

### Inclusion and Exclusion Criteria

The PICOTS criteria used to screen articles for inclusion/exclusion at both the title-and-abstract and full-text screening stages are detailed in Table 2.

Table 2 Inclusion and exclusion criteria

Study Characteristic | Inclusion Criteria | Exclusion Criteria
Population | - KQ 1: Patients with suspected pulmonary arterial hypertension (PAH) or asymptomatic patients at high risk for PAH (e.g., patients with a collagen vascular disorder such as scleroderma); - KQs 2 and 3: Patients with PAH | KQ 1: Patients have neither (1) a condition associated with a high risk of undiagnosed PAH (e.g., a collagen vascular disorder) nor (2) signs or symptoms suspicious for PAH KQ 2 and KQ 3: No patients have PAH
Interventions | - KQ 1 (screening): Echocardiography plus biomarkers including natriuretic peptides (e.g., atrial natriuretic peptide, brain natriuretic peptide), endothelin-1, uric acid, troponin T, nitric oxide, asymmetric dimethylarginine, cyclic guanosine monophosphate, D-dimer, and serotonin; - KQ 2 (management):; ○ Biomarkers plus clinical assessment (e.g., history, physical exam, functional status); ○ Echocardiography plus biomarkers plus clinical assessment; - KQ 3 (pharmacotherapies):; ○ Calcium channel blockers (amlodipine, diltiazem, nifedipine, verapamil); ○ Prostanoids (epoprostenol, treprostinil, iloprost); ○ Endothelin antagonists (bosentan, ambrisentan); ○ Phosphodiesterase inhibitors (sildenafil, tadalafil) | Study does not include a comparison of echocardiography or biomarkers for screening, diagnosis, or management of PAH, or does not include a comparison of monotherapy with combination therapy for PAH
Comparators | - KQ 1: Echocardiography vs. echocardiography plus biomarkers; - KQ 2:; ○ Echocardiography vs. biomarkers (direct comparison); ○ Echocardiography vs. echocardiography plus biomarkers (direct comparison); ○ Echocardiography vs. clinical assessment (indirect comparison); ○ Biomarkers vs. clinical assessment (indirect comparison); - KQ 3:; ○ One pharmacotherapy vs. another pharmacotherapy; ○ Monotherapy vs. combination therapy | Study does not include a comparison of echocardiography or biomarkers for screening, diagnosis, or management of PAH, or does not include a comparison of monotherapy with combination therapy for PAH
Outcomes | - KQ 1: Test-associated outcomes: Diagnostic accuracy efficacy (sensitivity, specificity, positive predictive value/negative predictive value); verification by right heart catheterization for test positive patients was required (incomplete verification of test negative patients was allowed); - KQ 2: Efficacy outcomes:; ○ Diagnostic thinking efficacy and therapeutic efficacy (clinician judgment about diagnosis/prognosis, choice of treatment); ○ Patient outcome efficacy for intermediate-term outcomes (hemodynamic parameters, dyspnea, and 6-minute walk) and long-term outcomes (functional class, quality of life, right heart failure, and mortality); - KQ 3: Effectiveness of pharmacotherapies:; ○ Intermediate-term outcomes such as hemodynamic parameters, dyspnea, and 6-minute walk; ○ Long-term outcomes such as functional class, quality of life, right heart failure or right ventricular dysfunction, and mortality | No primary or secondary outcomes of interest are reported
Outcomes (safety) | - KQs 1 and 2: Adverse effects of echocardiography and biomarkers, such as bleeding, bruising, infection, and transient ischemic attack; - KQ 3: Adverse effects of pharmacotherapies (liver function abnormalities, headache, flushing, cough, epistaxis, dyspepsia, diarrhea, peripheral edema, nausea, nasal congestion, dizziness, syncope, hypoxia, increased international normalized ratio or prothrombin time) and parenteral therapy (line infection, site pain, abrupt catheter occlusion) | None
Timing | Intermediate-term (≤120 days) and long-term (>120 days) | None
Setting | - Inpatient and outpatient; - Specialty (pulmonary, cardiology, rheumatology) and primary care | None
Study design | - Randomized controlled trial, prospective or retrospective observational study, or registry; - Original data (or related methodology paper of an included article) for any of the screening or diagnostic tests listed in the KQs, or original data with intermediate-term or long-term outcomes associated with monotherapy or combination therapy for PAH; - Relevant systematic review or meta-analysis (used for background only); - All sample sizes | Not a clinical study (e.g., editorial, nonsystematic review, letter to the editor, case series)
Publications | - English-language only; - Peer-reviewed article; - KQs 1 and 2: Published January 1, 1995, to present; - KQ 3: Published January 1, 1990, to present | Given the high volume of literature available in English-language publications (including the majority of known important studies), non-English articles are excluded^b^

KQ = Key Question; PAH = pulmonary arterial hypertension

### Study Selection

Using the prespecified inclusion and exclusion criteria, titles and abstracts were examined independently by two reviewers for potential relevance to the Key Questions. Articles included by any reviewer underwent full-text screening. At the full-text screening stage, paired researchers independently reviewed the articles and indicated a decision to include or exclude the article for data abstraction. When the paired reviewers arrived at different decisions, we reconciled the difference through review and discussion or through a third-party arbitrator, if needed. Articles meeting eligibility criteria were included for data abstraction. Relevant systematic review articles, meta-analyses, and methods articles were flagged for hand-searching and cross-referencing against the library of citations identified through electronic database searching. All screening decisions were made and tracked in the DistillerSR database (Evidence Partners, Inc., Manotick, ON, Canada).

### Data Extraction

The investigative team created data abstraction forms and evidence table templates. Based on clinical and methodological expertise, two investigators were assigned to the research questions to abstract data from the eligible articles. One investigator abstracted the data, and the second overread the article and the accompanying abstraction to check for accuracy and completeness. Disagreements were resolved by consensus or by obtaining a third reviewer’s opinion if consensus was not reached between the first two investigators. To aid in both reproducibility and standardization of data collection, investigators received data abstraction instructions directly on each form created specifically for this project with the DistillerSR data synthesis software program (Evidence Partners Inc., Manotick, ON, Canada). Data reported only in graphs were estimated quantitatively using Engauge Digitizer version 4.1 software (www.digitizer.sourceforge.net).

We designed the data abstraction forms for this project to collect data required to evaluate the specified eligibility criteria for inclusion in this review, as well as demographic and other data needed for determining outcomes (intermediate outcomes, health outcomes, and safety outcomes). Although we recorded time to clinical worsening (TTCW) as an outcome, we did not analyze it separately in lieu of individual outcomes. As a composite outcome, we found TTCW problematic to assess because it (1) is reported only in relatively few recent studies, (2) is defined differently in different studies, and (3) assigns equal importance to different events in the composite (mortality, hospitalization, transplant). The safety outcomes were framed to help identify adverse events, including bleeding, bruising, infection, liver function abnormalities, headache, flushing, epistaxis, dyspepsia, diarrhea, peripheral edema, nausea, nasal congestion, dizziness, syncope, increased international normalized ratio or prothrombin time.

Data necessary for assessing quality and applicability, as described in the Methods Guide,20 were also abstracted. Before they were used, abstraction form templates were pilot tested with a sample of included articles to ensure that all relevant data elements were captured and that there was consistency and reproducibility between abstractors. Forms were revised as necessary before full abstraction of all included articles. Appendix B lists the elements used in the data abstraction forms. Appendix C contains a bibliography of all articles/studies included in this review, organized alphabetically by author.

## Quality (Risk-of-Bias) Assessment of Individual Studies

We evaluated the quality of individual studies by using the approach described in the Methods Guide.20 For studies of diagnostic tests (KQ 1 and KQ 2), we used QUADAS-2,^23^ a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. QUADAS-2 describes risk of bias in four key domains: patient selection, index test(s), reference standard, and flow and timing; each domain is rated as high, low, or unclear risk of bias. For studies of pharmacotherapies, we used the Cochrane Risk of Bias tool, which evaluates random sequence generation, allocation concealment, blinding of participant and personnel, blinding of outcome assessment, incompleteness of outcome data, selective outcome reporting, and other bias.

Two raters independently evaluated each study and differences were resolved by consensus; if consensus could not be reached, then the item was rated as unclear, and the rationale for each differing assessment was described. Results were described for individual domains. If the distribution of ratings permits, methodological domains were examined for association with effects in meta-analysis.

To indicate the summary judgment of the quality of the individual studies, we used the summary ratings of good, fair, or poor based on their adherence to well-accepted standard methodologies and adequate reporting (Table 3).

Table 3 Definitions of overall quality ratings

Quality Rating | Description
Good | A study with the least bias; results are considered valid. A good study has a clear description of the population, setting, interventions, and comparison groups; uses a valid approach to allocate patients to alternative treatments; has a low dropout rate; and uses appropriate means to prevent bias, measure outcomes, and analyze and report results.
Fair | A study that is susceptible to some bias but probably not enough to invalidate the results. The study may be missing information, making it difficult to assess limitations and potential problems. As the fair-quality category is broad, studies with this rating vary in their strengths and weaknesses. The results of some fair-quality studies are possibly valid, while others are probably valid.
Poor | A study with significant bias that may invalidate the results. These studies have serious errors in design, analysis, or reporting; have large amounts of missing information; or have discrepancies in reporting. The results of a poor-quality study are at least as likely to reflect flaws in the study design as to indicate true differences between the compared interventions.

Included meta-analyses were appraised according to criteria adapted from the PRISMA Statement.21 Grading was outcome-specific; thus, a given study may have been graded of different quality for two individual outcomes reported within that study. Study design also was considered when grading quality. RCTs were graded as good, fair, or poor. Observational studies were graded separately, also as good, fair, or poor. Appendix D summarizes our assessment of the quality and applicability for each included study.

## Data Synthesis

Quantitative synthesis (i.e., meta-analysis) was done when we found multiple studies of similar design, population, intervention, comparator and outcome that reported sufficient data for analysis. When a meta-analysis was appropriate, we used random-effects models to quantitatively synthesize the available evidence. We use meta-analyses both to quantify and to attempt to explain between-study variation as well as to calculate summary estimates. When a meta-analysis was not appropriate, we described the reasons, presented data in tabular form, and summarized studies either individually or qualitatively.

For sensitivity and specificity data, we used a binomial model to calculate summary estimates of sensitivity and specificity and associated confidence intervals and summary ROC curve using SAS. Sensitivity analyses were conducted using summary receiver operating characteristic meta-analysis using the diagnostic odds ratio with dr-ROC software (Diagnostic Research Design and Reporting; Glenside, PA). For meta-analysis of correlation coefficients and hazard ratios for observational studies, we used a random effects model implemented in SAS (SAS Institute Inc.; Cary, NC). For treatment effects meta-analysis, we used a random effects model meta-analysis implemented in Comprehensive Meta-Analysis Software (Version 2.2.064, Biostat; Englewood, NJ). We tested for heterogeneity using graphical displays and test statistics (Q and I^2^ statistics), while recognizing that the ability of statistical methods to detect heterogeneity may be limited, particularly when the number of studies is small. We present summary estimates and confidence intervals in our data synthesis.

## Strength of the Body of Evidence

The strength of evidence for each Key Question was assessed using the approach described in the Methods Guide.24 The evidence was evaluated using the four required domains: risk of bias, consistency, directness, and precision (Table 4).

Table 4 Strength of evidence required domains

Domain | Rating | How Assessed
Risk of bias | Low Medium High | Assessed primarily through study design (RCT versus observational study) and aggregate study quality
Consistency | Consistent Inconsistent Unknown/not applicable | Assessed primarily through whether effect sizes are generally on the same side of “no effect” and the overall range of effect sizes
Directness | Direct Indirect | Assessed by whether the evidence involves direct comparisons or indirect comparisons through use of surrogate outcomes or use of separate bodies of evidence
Precision | Precise Imprecise | Based primarily on the size of the confidence intervals of effect estimates

Additionally, when appropriate, the studies were evaluated for dose-response association, the presence of confounders that would diminish an observed effect, strength of association (magnitude of effect), and publication bias. These domains were considered qualitatively, and a summary rating of high, moderate, or low strength of evidence was assigned after discussion by two reviewers. In some cases, high, moderate, or low ratings were impossible or imprudent to make; for example, when evidence on the outcome was too weak, sparse, or inconsistent to permit any conclusion to be drawn. In these situations, a grade of insufficient was assigned. This four-level rating scale consists of the following definitions:

- High—High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
- Moderate—Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
- Low—Low confidence that the evidence reflects the true effect. Further research is likely to change the confidence in the estimate of effect and is likely to change the estimate.
- Insufficient—Evidence either is unavailable or does not permit estimation of an effect.

Diagnostic evaluation studies (KQs 1 and 2) are generally indirect, as the link between the test intervention and outcome is mitigated by prognosis, management, and the effectiveness of treatments. As a rule of thumb, we considered correlation coefficients greater than 0.7 as strong association, 0.40 to 0.69 as moderate, and less than 0.40 as weak. In our summary strength of evidence assessments for KQs 1 and 2, lack of directness was weighed less heavily and risk of bias most heavily. Thus, we allowed high strength of evidence levels despite the lack of directness among these studies.

## Applicability

We assessed applicability across our KQs using the PICOTS format as described in the Methods Guide.20,25 We used these data to evaluate the applicability to clinical practice, paying special attention to study eligibility criteria, demographic features of the enrolled population (such as age, ethnicity, and sex) in comparison with the target population, version or characteristics of the intervention used in comparison with therapies currently in use (such as specific components of treatments considered to be supportive therapy), and clinical relevance and timing of the outcome measures. We summarized issues of applicability qualitatively. Because applicability issues may differ for different users, we reported across a range of potential applicability issues (Appendix D).

In diagnostic evaluation studies, we were particularly concerned with the prevalence of PAH versus PH in the study populations compared, the spectrum of underlying type of PAH, and the assessment of adverse events associated with testing. In PAH drug trials, we were particularly concerned with assessing the severity of illness; use of run-in periods and attrition before randomization; use of surrogate or combined outcome measures; short study duration; reporting of adverse events, in particular including those related to administration or monitoring of treatment; sample size sufficient to assess minimally important differences from a patient perspective; and use of intention-to-treat-analysis.

## Peer Review and Public Commentary

The peer review process is our principal external quality-monitoring device. Nominations for peer reviewers were solicited from several sources, including the TEP and interested Federal agencies. Experts in cardiology, radiology, vascular surgery, general medicine, and nursing, along with individuals representing stakeholder and user communities, were invited to provide comments; AHRQ and an associate editor also provided comments. The draft report was posted on the AHRQ Web site for 4 weeks, from August 31 to September 28, 2012. We have addressed reviewer comments, revising the report as appropriate, and have documented our responses in a disposition of comments report available on the AHRQ Web site. A list of peer reviewers is given in the preface of this report.