# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential non-financial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential non-financial conflicts of interest identified.

The list of Peer Reviewers follows:

- Nicholas Hill, M.D.
  Pulmonary and Critical Care Division
  New England Medical Center
  Tufts University School of Medicine
  Boston, MA
- Alan L. Hinderliter, M.D.
  Cardiologist and Internist
  Associate Professor of Medicine
  University of North Carolina School of Medicine
  Chapel Hill, NC
- Bryan H. Ristow, M.D.
  Internal Medicine, Cardiovascular Disease
  California Pacific Medical Center
  San Francisco, CA