# Discussion

## Key Findings and Strength of Evidence

In this comparative effectiveness review, we included 60 studies involving 7096 patients that evaluated biomarker tests, echocardiography, or both, to screen for PAH (KQ 1); 99 studies involving 8655 patients that evaluated biomarker tests, echocardiography, or both, to diagnose and follow progression of disease as well as response to therapy for PAH (KQ 2); and 37 studies involving 4192 patients that assessed the effectiveness of drug treatments for PAH in adults.

### KQ 1 Screening for PAH

We found 1 study involving 372 patients that evaluated the combination of biomarker tests and echocardiography to echocardiography alone to screen for PAH (Key Question [KQ] 1). Based on one good-quality prospective cohort study, biomarker testing with NT-proBNP may be useful in ruling out PAH among those suspected of PH who also have elevated sPAP by echocardiography;26 however, no data are available regarding combined echocardiography and biomarker screening in asymptomatic patients at high risk for PAH. In the absence of other direct comparative trials, we attempted to address this question by evaluating the efficacy of biomarker and echocardiography independently for screening and diagnosis of PAH. We reviewed 60 studies involving 7096 patients that evaluated biomarker tests, echocardiography, or both, to screen for PAH. The associations between natriuretic peptide testing and PAH diagnosis is insufficiently strong to support its use alone as a screening test in either asymptomatic or symptomatic patients suspected of PAH. Data on biomarker testing were essentially limited to a single test—NT-proBNP—which showed only moderate correlation with RHC hemodynamic measures and showed a great deal of variability between studies in its diagnostic accuracy and discrimination.

We found that echocardiography estimates of pulmonary artery pressures (sPAP, TG, and TRV) and pulmonary vascular resistance (TRV/VTI_RVOT_) demonstrated good accuracy in screening for PAH. In low prevalence populations (<10%), negative predictive value of a normal sPAP is high, suggesting that echocardiography with a low threshold may be an appropriate test in asymptomatic high-risk populations or in patients with symptoms suggesting PAH. (This is shown in studies of liver transplant studies with complete verification).

Our findings suggest that echocardiographic estimation of sPAP may be sufficiently accurate to justify its role in screening for PAH in symptomatic patients suspected of having PH. However, this conclusion has several important caveats. First, echocardiography in a small, but significant, number of patients may not produce an estimate of sPAP because of poor-quality Doppler visualization of the tricuspid regurgitant jet. Second, echocardiographic estimates of sPAP often over- or under-estimate pulmonary artery pressure enough to result in misclassification according to PAH diagnostic threshold—hence the selection of a test threshold is critical for the aim of screening. A single test threshold is insufficient to perform with simultaneously high sensitivity and specificity (or PPV and NPV), especially in populations with higher risk or higher prevalence (more symptomatic), where echocardiography cannot be relied upon to exclude pulmonary hypertension if pretest probability is high. In asymptomatic patients at high risk for PH, echocardiography seems to perform with similar sensitivity and specificity; however, these studies suffer from verification bias, which likely inflates both the sensitivity and specificity estimates. Two prospective studies that show approximately 10 percent of asymptomatic patients with systemic sclerosis and normal sPAP develop PH when serially retested with echocardiography are consistent with either misclassification at baseline echocardiographic screening or prospective development of PH. This would suggest that if echocardiographic screening of asymptomatic patients with a high-risk diagnosis were to be undertaken, then serial testing would be necessary.

Table 32 summarizes the findings of our review and the strength of evidence (SOE) for the available outcomes of sensitivity, specificity, correlation coefficients, and adverse effects of biomarker and echocardiographic tests.

Table 32 Summary of strength of evidence and effect estimates for echocardiography vs. echocardiography plus biomarkers as screening modalities for PAH (KQ 1)^a^

Test | Sensitivity | Specificity | Correlation with RHC
Echo sPAP with NT-proBNP versus Echo sPAP in symptomatic patients | SOE = Insufficient (1 study, 121 patients) NT-proBNP >80 pg/mL has a low false negative rate compared with RHC reference standard; the serial testing study design did not allow for NT-proBNP testing to improve sensitivity beyond that of echo sPAP alone | SOE = Low (1 study, 121 patients) NT-proBNP ≤80 pg/mL ruled out PAH in 9–16% of patients with elevated echo sPAP ≥36 mmHg | SOE = Insufficient (No studies)
Echo sPAP with NT-proBNP versus Echo sPAP in asymptomatic patients | SOE = Insufficient (No studies) | SOE = Insufficient (No studies) | SOE = Insufficient (No studies)
NT-proBNP compared with RHC | SOE = Low (3 studies, 198 patients) NT-proBNP has variable sensitivity (range, 56% to 100%) for diagnosing PAH; uncertain performance for ruling out PAH | SOE = Low (3 studies, 198 patients) NT-proBNP has variable specificity (range, 24% to 95%); uncertain performance for ruling in PAH | SOE = Moderate (3 studies, 176 patients) Correlation of NT-proBNP and RHC is only moderate (range, 0.43 to 0.72)
TRV/TG/sPAP compared with RHC | SOE = Moderate (19 studies, 2459 patients) Echocardiographic estimate of sPAP showed variable sensitivity ranging from 58% to 100%, with lower prevalence studies finding higher sensitivity | SOE = Moderate (19 studies, 2459 patients) Echocardiographic estimate of sPAP showed variable specificity ranging from 50% to 98%, with lower prevalence studies finding higher specificity | SOE = Moderate (23 studies, 4217 patients) Echocardiographic estimates of sPAP showed moderate to strong correlation (range, 0.38 to 0.96) with RHC and were on average unbiased, but were limited by imprecision and by a significant minority of patients in whom TRV was not measurable
TRV/VTI_RVOT_ compared with RHC | SOE = Moderate (6 studies, 196 patients) Echocardiographic estimate of PVR showed reasonably high sensitivity (range, 89% to 100%) for ruling in PAH | SOE = Moderate (6 studies, 196 patients) Echocardiographic estimate of PVR showed variable specificity (range, 50% to 97%), with better specificity in lower prevalence studies (range, 94% to 97%) | SOE = High (6 studies, 196 patients) Strong correlation between echocardiographic estimates of PVR and PVR by RHC (range, 0.74 to 0.84)

NT-proBNP = N-terminal pro-B-type natriuretic peptide; RHC = right heart catheterization; SOE = strength of evidence; sPAP = systolic pulmonary artery pressure; TRV = tricuspid regurgitant jet velocity; VTI_RVOT_ = velocity-time integral of right ventricular outflow tract

a Gray background indicates insufficient SOE.

### KQ 2 Management of PAH

Currently, right heart catheterization (RHC) is the reference standard for diagnosing and monitoring progression of PAH. Several biomarkers and echocardiographic parameters have been proposed as potential alternatives to frequent RHC monitoring. In KQ 2 we reviewed studies that evaluated the most commonly studied biomarkers (natriuretic peptides, endothelin-1, uric acid, troponin T, nitric oxide, asymmetric dimethylarginine, cyclic guanosine monophosphate, and D-dimer) and echocardiographic parameters (RV size, RA size, FAC, TAPSE, RIMP/MPI/Tei index, sPAP, mPAP, TR jet, peak TR jet, RVOT, RVEF, RVSP or pericardial effusion) to determine the ability of these measures to assess severity of disease, predict mortality or lung transplantation, or assess response to therapy.

In studies evaluating correlation of the above measures with RHC measures or a commonly used measure of disease severity (6MWD) studies were too underpowered to give reliable results. However, by combining studies looking at the same parameters and performing a meta-analysis we were able to increase the power for seven different comparisons: (1) BNP versus RHC-mPAP, (2) BNP versus RHC-PVR, (3) BNP versus RHC-CI, (4) BNP versus RHC-RAP, (5) BNP versus RHC-PCWP, (6) BNP versus 6MWD, and (7) echocardiography-derived sPAP versus RHC-sPAP. BNP showed only moderate correlation with most RHC measures (mPAP, PVR, cardiac index, RAP) and clinical measures of disease severity (6MWD) and showed weak correlation with PCWP. Most effect estimates were precise (mPAP, PVR, CI, RAP, 6MWD), but estimates for PCWP were imprecise, making it difficult to interpret the clinical importance of the findings for this measure. For the other measures, correlation with BNP was moderate, indicating that BNP levels alone could not serve as an accurate surrogate marker for disease severity. Echocardiography-derived sPAP showed strong correlation with RHC-sPAP, although there was a great deal of heterogeneity among these studies and only moderate strength of evidence to support the use of this measure.

In studies evaluating the ability of biomarkers or echocardiographic measures to predict mortality, we were able to perform a meta-analysis on six measures: BNP, pericardial effusion, RA size, FAC, uric acid and TAPSE. BNP level and pericardial effusion were strong predictors of mortality. RA size was also predictive of mortality. Data on uric acid suggested an association with mortality, while fractional area change (FAC) showed uncertain association with mortality.

The remaining studies that were not included in the meta-analyses were considered to provide insufficient evidence due to small size and poor quality.

Several studies evaluated mean or median levels of biomarkers or echocardiographic parameters at various points in time or as a change from baseline to evaluate response to therapy. Due to the small number and heterogeneity of these studies, we were unable to perform meta-analysis on these data. While a few studies found changes in biomarkers or echocardiographic parameters in response to various treatments, there were insufficient data to quantitatively assess overall response or to recommend use of these markers as surrogate outcomes measures.

We found no studies addressing diagnostic thinking efficacy, therapeutic efficacy, or safety concerns with echocardiography or biomarkers.

The strength of evidence (SOE) ratings for the most commonly reported biomarkers and echocardiographic parameters are summarized in Table 33 (management of PAH) and Table 34 (prediction of patient outcomes).

Table 33 Summary of strength of evidence and effect estimates for the use of echocardiography or biomarkers in the management of PAH (KQ 2)

Comparison | Number of Studies (Patients) | Summary Correlation Coefficient Estimate (95% CI) | SOE and Findings
BNP compared with RHC-mPAP | 14 (606) | 0.39 (0.31 to 0.47) | SOE = Moderate Serum BNP level shows moderate correlation with mPAP
BNP compared with RHC-PVR | 13 (684) | 0.46 (0.31 to 0.59) | SOE = Low Serum BNP level shows moderate correlation with PVR
BNP compared with RHC-RAP | 12 (645) | 0.47 (0.40 to 0.54) | SOE = Moderate Serum BNP level shows moderate correlation with RAP
BNP compared with RHC-CI | 10 (550) | −0.42 (−0.54 to −0.28) | SOE = Low Serum BNP level shows negative moderate correlation with cardiac index
BNP compared with PCWP | 5 (319) | 0.16 (0.01 to 0.31) | SOE = Low Serum BNP level shows poor correlation with PCWP
BNP compared with 6MWD (absolute) | 9 (484) | −0.46 (−0.55 to −0.35) | SOE = Moderate Serum BNP level shows negative moderate correlation with 6MWD
Echocardiography-derived sPAP compared with RHC-sPAP | 9 (362) | 0.76 (0.53 to 0.89) | SOE = Low sPAP estimated by echocardiography shows good correlation with sPAP from RHC

6MWD = 6-minute walk distance; BNP = B-type natriuretic peptide; CI = confidence interval; FAC = fractional area change; PCWP = pulmonary capillary wedge pressure; PVR = pulmonary vascular resistance; RA = right atrium; RAP = right atrial pressure; RHC = right heart catheterization; SOE = strength of evidence; sPAP = systolic pulmonary artery pressure

Table 34 Summary of strength of evidence and effect estimates for the use of echocardiography or biomarkers in the prediction of mortality (KQ 2)^a^

Marker | Number of Studies (Patients) | Summary Hazard Ratio Estimate (95% CI) | SOE and Findings
BNP | 6 (407) | 2.42 (1.72 to 3.41) | SOE = Moderate Increase in log-transformed BNP level is a good predictor of mortality
Pericardial effusion | 8 (2590) | 2.43 (1.57 to 3.77) | SOE = Moderate Presence of pericardial effusion is a strong predictor of mortality, although there was wide variability in results for this measure
RA size | 4 (242) | 1.06 (1.01 to 1.10) | SOE = Moderate RA size is a predictor of mortality
FAC | 4 (242) | 0.98 (0.96 to 1.01) | SOE = Moderate FAC is a poor predictor of mortality
Uric acid | 4 (246) | 1.01 (1.00 to 1.01) | SOE = Low Small increase in mortality but imprecision of estimates limit these data
TAPSE | 4 (251) | 0.94 (0.82 to 1.08) | SOE = Insufficient Inconsistent results between studies lead to uncertainty

BNP = B-type natriuretic peptide; CI = confidence interval; FAC = fractional area change; RA=right atrium; RAP = right atrial pressure; SOE = strength of evidence

a Gray background indicates insufficient SOE.

### KQ 3 Pharmacotherapy for PAH

The treatment options for PAH currently are based on three main classes of drugs: endothelin receptor antagonists (ambrisentan, bosentan); phosphodiesterase-5 inhibitors (sildenafil, tadalafil); and prostacyclin-analogues (epoprostenol, iloprost, treprostinil). Few RCTs have been performed to date to fully evaluate the efficacy of these drugs—individually or in combination.

We reviewed 28 RCTs studies involving 3613 patients and 9 nonrandomized observational studies involving 579 patients that assessed the effectiveness of drug treatment for PAH in adults. Our review found inconclusive evidence regarding mortality reduction for 11 of the 12 drug treatment comparisons:

- Ambrisentan versus placebo (OR 0.40; 95% CI, 0.10 to 1.51)
- Bosentan versus placebo (OR 0.72; CI, 0.14 to 3.60)
- Epoprostenol versus placebo or standard therapy (OR 0.33; CI, 0.07 to 1.50)
- Iloprost versus placebo (OR 0.43; CI, 0.08 to 2.47)
- Sildenafil versus placebo (OR 1.01; CI, 0.10 to 9.92)
- Tadalafil versus placebo (OR 0.50; CI, 0.05 to 5.63)
- Treprostinil versus placebo (OR 0.50; CI, 0.12 to 2.12)
- Vardenafil versus placebo (OR 0.08; CI, 0.00 to 1.82)
- Endothelin antagonists versus placebo (OR 0.60; CI, 0.23 to 1.59)
- Phosphodiesterase inhibitors versus placebo (OR 0.30; CI, 0.08 to 1.11)
- Combination therapy versus monotherapy (OR 0.37; CI, 0.04 to 3.32)

However, for prostanoids versus placebo or standard therapy, there was a statistically significant improvement in mortality (OR 0.52; CI, 0.29 to 0.95, low strength of evidence). Few deaths were observed in these limited-duration studies, leading to wide confidence intervals and lack of statistical power to detect a difference; however, a consistent direction of effect and demonstrated improvements in other outcomes, including functional and hemodynamic measures, support that a mortality reduction might exist.

The combination therapy analyzed included three different combinations of drugs: sildenafil plus IV epoprostenol versus IV epoprostenol plus placebo; bosentan plus IV epoprostenol versus IV epoprostenol plus placebo; and bosentan or sildenafil plus inhaled treprostinil versus bosentan or sildenafil plus placebo. Our results are similar to a recent meta-analysis by Fox et al.,210 which found no significant change in mortality with combination therapy compared with monotherapy for PAH (OR 0.42; 95% CI, 0.08 to 2.26). Clearly more studies are needed in this area.

In studies evaluating 6MWD, we performed four meta-analyses: (1) endothelin receptor antagonists versus placebo, (2) phosphodiesterase-5 inhibitors versus placebo, (3) prostanoids versus placebo or standard therapy, and (4) combination therapy versus monotherapy. Increases in 6MWD ranging from 27.9 meters (95% CI, 10.3 to 45.4) to 39.9 meters (CI, 21.4 to 58.4) were observed in trials of all drug classes when compared with placebo or standard therapy; however, comparisons between agents are inconclusive. The magnitude of these statistically significant improvements in 6MWD associated with treatment are very close to a recently published estimate of 33 meters for the minimal important difference for the 6MWD in patients with PAH.211 Combination therapy also showed improved 6MWD compared with monotherapy (OR 23.9; CI, 8.0 to 39.9), but the diversity of treatment regimens and the small number of combination therapy trials again make comparisons between specific regimens inconclusive.

In studies evaluating hospitalization, we performed four meta-analyses: (1) endothelin receptor antagonists versus placebo, (2) phosphodiasterase-5 inhibitors versus placebo, (3) prostanoids versus placebo, and (4) combination therapy versus monotherapy. In patients taking the endothelin receptor antagonists and phosphodiesterase-5 inhibitors, the odds ratio of hospitalization was lower compared with placebo (OR 0.34 and 0.48, respectively). The magnitude of the odds ratio associated with prostanoids was similar (OR 0.42), but the 95% confidence interval included 1.0, thereby making this finding not statistically significant and inconclusive. Combination therapy compared with monotherapy also showed a similar nonsignificant effect on hospitalization (OR 0.64).

In studies using right heart catheterization to follow response to therapy, we performed meta-analyses on the following outcomes: (1) pulmonary vascular resistance, (2) mean pulmonary artery pressure, and (3) cardiac index. We found modest improvements in all three measures associated with phosphodiesterase inhibitors and prostanoids and improvements in two measures (mPAP and cardiac index) associated with endothelin antagonists. The clinical significance of the magnitude of the observed changes is unclear. Meta-analysis of two studies that compared combination therapy with monotherapy revealed a modest but statistically significant improvement in mPAP associated with combination therapy and insufficient evidence for PVR and cardiac index.

In studies reporting adverse effects, we found that phosphodiesterase-5 inhibitors were more likely to cause headache than endothelin receptor antagonists were, and endothelin antagonists still were more likely to cause headache than placebo. Drugs did not significantly differ in their odds of causing dizziness or diarrhea. Aerosolized prostanoids were much more likely to cause jaw pain and cough compared with placebo. Phosphodiesterase-5 inhibitors and prostanoids were associated with flushing, while data on endothelin receptor antagonists were inconclusive. Phosphodiesterase-5 inhibitors had a significant association with peripheral edema while data on prostanoids and endothelin receptor antagonists were inconclusive.

The strength of evidence (SOE) ratings are summarized in Table 35.

Table 35 Summary of strength of evidence and effect estimates for monotherapy versus combination therapy for PAH (KQ 3)^a^

Intervention | Mortality | 6MWD (m) | Hospitalization
Endothelin antagonist vs. placebo | SOE = Insufficient (6 studies, 838 patients) Inconclusive benefit (few studies, few deaths lead to wide CI) OR 0.60 (95% CI, 0.23 to 1.59) | SOE = Moderate (6 studies, 663 patients) Improved 6MWD with endothelin antagonists compared with placebo Mean difference 39.9 (95% CI, 21.4 to 58.4) | SOE = Moderate (3 studies, 606 patients) Reduced risk of hospitalization OR 0.34 (95% CI, 0.17 to 0.69)
Phosphodiesterase inhibitors vs. placebo | SOE = Insufficient (4 studies, 1,011 patients) Inconclusive benefit (few studies, few deaths lead to wide CI) OR 0.30 (95% CI, 0.08 to 1.11) | SOE = Moderate (4 studies, 991 patients) Improved 6MWD with PDE5 therapy compared with placebo or standard therapy Mean difference 38.9 (95% CI, 22.0 to 55.9) | SOE = Moderate (4 studies, 1,011 patients) Reduced risk of hospitalization OR 0.48 (95% CI, 0.25 to 0.91)
Prostanoids vs. placebo or standard therapy | SOE = Low (8 studies, 1,229 patients) Lower mortality with prostanoids, but inconsistent results and wide CI OR 0.52 (95% CI, 0.29 to 0.95) | SOE = Moderate (7 studies, 933 patients) Improved 6MWD with prostanoid therapy compared with placebo Mean difference 27.9 (95% CI, 10.3 to 45.4) | SOE = Insufficient (2 studies, 301 patients) Inconclusive benefit (few studies, wide CI) OR 0.42 (95% CI, 0.06 to 3.08)
Combination vs. monotherapy | SOE = Insufficient (3 studies, 566 patients) Inconclusive benefit (few studies, few deaths lead to wide CI) OR 0.37 (95% CI, 0.04 to 3.32) | SOE = Low (3 studies, 363 patients) Improved 6MWD with combination therapy compared with monotherapy Mean difference 23.9 (95% CI, 8.0 to 39.9) | SOE = Insufficient (3 studies, 566 patients) Inconclusive benefit (few studies, wide CI) OR 0.64 (95% CI, 0.31 to 1.36)

6MWD = 6-minute walk distance; CI = confidence interval; NS = not statistically significant; OR = odds ratio; SOE=strength of evidence

a Gray background indicates insufficient SOE.

### Findings in Relation to What is Already Known

Two previous meta-analyses of echocardiography for diagnosing pulmonary hypertension, focusing solely on sPAP, drew similar conclusions to our review, despite methodological differences, suggesting that our findings are robust. Zhang et al.212 analyzed six studies, finding a summary sensitivity of 0.82 (95% CI; 0.76 to 0.88) and summary specificity of 0.68 (95% CI, 0.64 to 0.72). These estimates are somewhat lower that our findings. Despite inclusion criteria that seem to be similar, Zhang et al.212 included fewer eligible studies than our review even taking into account the date range. Another more recent analysis that included more studies had broader inclusion criteria including patients with COPD and heart failure who were not suspected of having PAH.213 Summary estimates of sensitivity of 0.83 (CI, 0.73 to 0.90) and specificity of 0.72 (CI, 0.53 to 0.85) were closer to our findings. This study found significant heterogeneity and, given larger numbers of included studies, was able to undertake various sensitivity analyses to explore the reasons for heterogeneity; however, none of the characteristics examined—including prospective studies, study year, population (cardiac versus lung), interval between echocardiography and RHC, and method of RAP estimate—revealed a source for the heterogeneity. Both reviews concluded that echocardiography has acceptable accuracy for use as the initial measure of pulmonary pressures in evaluating patients in whom PH is suspected, but not sufficient accuracy to diagnose PH without RHC.

KQ 2 focused on determining whether echocardiographic parameters and/or biomarkers have value in the management of PAH. The current guidelines for diagnosis and treatment of pulmonary hypertension have identified the presence of pericardial effusion, indexed right atrial area, LV eccentricity index, and RV Doppler index (RIMP/MPI/Tei index) as the echocardiographic parameters having the best prognostic value. TAPSE has also been reported to have some prognostic value.12 Our findings confirm that pericardial effusion and right atrial size were strong predictors of mortality; however, we found TAPSE did not predict mortality, and we had insufficient data to evaluate the prognostic value of LV eccentricity index or RV Doppler index. These guidelines have also reported that uric acid, ANP, BNP, and troponin T have prognostic value in PAH. In our review, BNP level was associated with mortality and also showed moderate correlation with hemodynamic measures such as RAP and PVR as well as clinical outcomes such as the 6MWD, which have all been reported by the current guidelines to be strong predictors of prognosis. Prior studies also have attempted to determine an optimal cutoff point for BNP levels to most accurately predict prognosis, but we had insufficient data to make any such determination. We also had insufficient data to determine the prognostic significance of other biomarkers. We did find that echocardiography-derived sPAP correlated strongly with RHC-sPAP, but given that sPAP is considered less important than mPAP in terms of prognostic value for PAH, this correlation may be of limited clinical utility.

For KQ 3, our results are similar to a recent meta-analysis by Fox et al.,210 which found no significant change in mortality with combination therapy compared with monotherapy for PAH (RRR 0.42; 95% CI, 0.08 to 2.26). Our assessment resulted in minor differences that did not impact the conclusions of the study, including a reversal of the effect direction in one study of 6MWD192 and inability to reproduce the mortality data from another study.209 Our findings are consistent with those of another meta-analysis of similar scope that also reported a significant effect of prostanoids on mortality.214

Another finding from Fox et al. suggested a relationship between the efficacy of treatment on mortality and functional class severity in individual trials. A meta-regression showed greater reduction in mortality in trials with higher proportions of functional class III or IV patients (R^2^=0.51). We reexamined this hypothesis in our set of data, which included several more trials with lower proportions of functional class III or IV patients. We found no significant association (p=0.82) (Figure 42).

Figure 42 Regression of functional class on log odds ratio

Figure 42. Regression of functional class on log odds ratio. This figure shows a regression of functional class on log odds ratio. A finding from Fox et al. suggested a relationship between the efficacy of treatment on mortality and functional class severity in individual trials. A meta-regression showed greater reduction in mortality in trials with higher proportions of functional class III or IV patients (R2=0.51). We reexamined this hypothesis in our set of data, which included several more trials with lower proportions of functional class III or IV patients. We found no significant association (p=0.82)

### Applicability

The principal limitations to applicability of data on the diagnosis of PAH all relate to the patient populations studied. First, the studies may not be applicable to the screening of asymptomatic patients. None of the study populations consisted entirely of asymptomatic patients and, although many studies included some patients without symptoms, they were not reported separately in terms of outcomes. Some studies of populations in whom PAH was suspected failed to adequately describe the basis for a clinical suspicion of PAH, whether symptoms of dyspnea, clinical signs, or other test results, such as diffusion capacity of the lung for carbon monoxide (DLCO), thus also limiting the applicability of these studies for screening symptomatic patients. Second, the spectrum of disease among study populations was often skewed, particularly in case-control studies, by selection criteria that selected from patients with known PAH (cases) and patients known not to have PAH (controls). Such studies usually excluded participants with other conditions that might be confused with PAH such as PH due to left-sided heart failure, thrombotic disease, or chronic obstructive pulmonary disease. Third, participants in many studies had a wide range of disease severity, particularly those cases in case-control design studies, which is a poor match for the question at hand. Other applicability issues identified in the KQ 1 studies were less frequent and judged to be less severe.

Our findings in KQ 2 assessing the prognostic or predictive value of biomarkers and echocardiography may not be applicable to all PAH populations. The greatest concern is that studies in KQ 2 included participants at widely differing points in the natural history of disease, who had widely differing degrees of disease severity and different underlying etiologies of PAH. There was also concern that the population was not adequately described to assess applicability, included patients with conditions other than PAH, or in general did not match the review question. Applicability may also be limited by the use of surrogate markers that may not be clinically relevant and insufficient followup time. In a few studies, it was also felt that the intervention arm or cointerventions did not adequately reflect current clinical practice or that the study setting was widely divergent from the current typical U.S. setting. Finally, there is concern that some studies did not provide adequate information about adverse events.

Applicability considerations were somewhat different for KQ 3 than for the Key Questions about screening and management of PAH. Most of the studies included in this review for KQ 3 were RCTs with generally good internal validity. Patient populations, however, differed between studies; variation in eligibility criteria resulted in differences between study populations in severity of illness, underlying etiology of PAH, comorbid conditions, and prior and concurrent treatment. Many different countries were represented, thereby introducing potential differences in clinical practice and care delivery settings relative to current practice in typical settings the U.S. There was also concern that the population was not always adequately described to assess applicability, with few studies exploring potential differences in response to treatment among different patient subgroups.

## Implications for Clinical and Policy Decisionmaking

With regard to screening for PH with echocardiography, our findings are generally consistent with the approach used in the guidelines from the European Society of Cardiology (ESC)/European Respiratory Society (ERS),12,215 which describe a stratification based on echocardiographic TRV or sPAP and other echocardiographic variables suggestive of pulmonary hypertension (PH):

- PH unlikely: TRV ≤2.8 m/s or sPAP ≤36 mmHg and no additional echocardiographic variable suggestive of PH
- PH possible: TRV ≤2.8 m/s or sPAP ≤36 mmHg but with additional echocardiographic variable suggestive of PH or TRV 2.9–3.4 m/s or sPAP 37–50 mmHg
- PH likely: TRV >3.4 m/s or sPAP >50 mmHg

The additional echocardiographic variables include increased velocity of pulmonary valve regurgitation and a short acceleration time of RV ejection into the PA. The guideline noted that RA and RV dilation, abnormal septum shape or function, increased RV wall thickness, and dilated main PA occur late in the course of PH and thus have questionable value in screening.

The guideline specifically recommends against screening to identify mild, asymptomatic PH because of the high frequency of both underestimation and overestimation of pulmonary artery pressures by echocardiography. Hence, the thresholds are set high. This guideline recommends that echocardiography always be performed when PH is suspected. Also recommended is echocardiographic screening of patients who are candidates for liver transplantation and symptomatic patients with liver disease, connective tissue diseases, HIV infection, and lung disease. The only suggestion for screening asymptomatic patients is for patients with the scleroderma spectrum of diseases, in whom screening “may be considered.” The lack of direct comparisons between assessment strategies, and the lack of measures of clinical outcomes associated with screening diagnostic or prognostic testing, would not seem to support more directive recommendations regarding testing modalities.

Our findings support using echocardiography or biomarkers to assess disease severity, prognosis, or response to therapy. Echocardiography-derived sPAP shows promise as a possible surrogate marker for RHC-sPAP, but whether or not this measure alone is adequate to assess disease severity, prognosis, or response to therapy is unclear, and so this evidence is insufficient to support recommendations regarding policy changes.

The findings from our meta-analyses of the few studies that compared combination therapy with monotherapy suggest, but do not prove, that combination therapy confers more benefit than does monotherapy in the treatment of PAH. These findings are generally consistent with the ESC/ERS guideline recommendation for monotherapy as initial treatment, with combination treatment reserved for patients who have an inadequate clinical response to monotherapy.12,215

## Limitations of the Comparative Effectiveness Review Process

The process of a comparative effectiveness review calls for specifying the scope and methods a priori. In this review, certain decisions made in designing the review resulted in limitations to this report. First, although we did not intend to exclude studies of children, some of the inclusion criteria we established had the effect of eliminating much of the literature on children with PAH. These criteria included the requirement for RHC verification of diagnoses of PAH and, for therapy trials, a minimum followup of 3 months. Studies in children, particularly newborns with PPHN, often omitted RHC and reported outcomes in shorter followup intervals. Second, we anticipated better quality data for the questions about screening and diagnosis (KQ 1) and prognosis (KQ 2) than we actually found.

For KQ 3, certain limitations existed in our search criteria, which may have limited the analysis. First, as with all meta-analyses, there is the potential for bias due to analyzing published studies, which are more likely to have positive results. We investigated this possibility by creating a funnel plot that included 17 of the 28 RCTs that met eligibility criteria for KQ 3 and that reported 6MWD as an outcome at 8 to 16 weeks after randomization to treatment. Visual inspection of the funnel plot suggests an absence of publication bias. We selected studies that reported 6MWD for this assessment of possible publication bias because this is the major outcome that was most commonly reported, and because there were too few studies that consistently reported other outcomes to reliably assess for possible publication bias. Another limitation is that we pooled the lower doses of drug with the higher doses, thereby possibly diluting any treatment effects—either beneficial or harmful—seen in the higher doses. We also may have missed lower doses that were less efficacious. Our analysis of the 6MWD outcome was also hindered by the heterogeneity in the ways studies were reported (mean versus median, and standard deviation versus standard error); we addressed this by converting medians to means and interquartile ranges to standard errors, but this required us to make assumptions about normal distribution of data.

## Limitations of the Evidence Base

Current evidence has several important limitations that preclude a firm conclusion about the effectiveness of echocardiography and biomarker screening for PAH. First, studies have most often assembled populations that reflect referral-filter bias and which inadequately document the presence of symptoms and signs related to PAH or to an alternative diagnosis such as congestive heart failure (CHF) or pulmonary fibrosis, etc. In such studies, we found that the diagnostic performance of echocardiographic testing varied with PAH prevalence such that higher prevalence was associated with poorer diagnostic performance. We believe this is related to a higher proportion of conditions that may be confused with PAH and which use screening tests that fail to distinguish these conditions (e.g., PCWP >15 mmHg can be easily found at RHC but is difficult to ascertain by echocardiography; BNP can be similarly elevated in CHF and PAH).

Second, the diagnosis of PAH is based on multiple components that include not only pulmonary artery pressure but also the absence of elevated PCWP and elevated PVR. However, nearly all studies of echocardiographic screening relied on the measurement of a single parameter—TRV—as the sole basis for calculation of TG. TG is the principal component for estimation of sPAP and is a key part of estimation of PVR as TRV/VTI_RVOT_. In theory, the use of ancillary data of a different sort, such as NT-proBNP, is potentially valuable as a diagnostic strategy.

One study that used serial application of echocardiography and biomarker testing (NT-proBNP) suggests that a combination of echocardiography and biomarker testing can work. With a goal of identifying patients with elevated echocardiography sPAP who could safely refrain from RHC, this study applied a low (highly sensitive) threshold for NT-proBNP and also used ECG evidence of RVH. However, this study was small and, like all of the other studies we identified, suffers from inadequate verification of disease status of at least some screening of test-negative patients.

Given the invasive nature of the RHC reference standard test, it is not surprising that many studies, especially those in lower risk screening populations, would shun widespread verification of test-negative patients. However, the selection of test-negative patients for verification when based on other clinical characteristics (such as DLCO measures or symptoms of dyspnea) was often inadequately reported to quantify the bias due to inadequate verification. None of the studies used an alternate reference standard for test-negative patients; however, two studies that sought to prospectively identify predictors of incident PAH provide valuable insight into this problem—suggesting that approximately 10 percent of echocardiography-screened negative SSc patients would meet PAH diagnostic criteria within 6 to 36 months.

The value of a screening test for early diagnosis depends not only on the diagnostic accuracy of the test for diagnosing the target condition but also the consequences of the different outcomes of testing. These consequences include (1) adverse effects of followup testing or treatment of patients with a false-positive screen and (2) outcomes for patients who go undiagnosed or untreated after a false-negative screen balanced against the benefits that accrue to patients with the target condition who may begin treatment earlier as a result of a true-positive screen. In the case of PAH, although we found no indication of harms related to the screening tests themselves, neither did we find information about the harms of subsequent diagnostic evaluation (such as RHC). Also, there are no clear data on benefits of early treatment or harms from delaying treatment. Thus the considerations are limited to the diagnostic accuracy of testing rather than a broader examination of a policy of screening for early identification.

The main focus of KQ 2 was to determine the comparative effectiveness of biomarkers, echocardiographic parameters, or the combination of both to manage PAH and affect diagnostic thinking efficacy, therapeutic efficacy, and patient outcome efficacy. None of the included studies addressed diagnostic thinking efficacy or therapeutic efficacy. Several studies evaluated changes in levels of biomarkers or echocardiographic parameters in response to therapy, but there were too few studies for any particular marker, as well as significant heterogeneity among studies, leading to insufficient evidence to assess patient outcome efficacy. In addition, no studies evaluated the combination of biomarkers and echocardiography in regard to management of PAH. While there were several studies included in the review that evaluated biomarkers, only BNP had a sufficient number of studies to allow meta-analysis. We limited the evaluation of biomarkers and echocardiographic parameters to those most widely studied; however, the literature review did reveal a wide range of other biomarkers and echocardiographic parameters in a limited number of studies that may be promising in the management of PAH. Further, while studies evaluating echocardiography or using RHC as a comparator reported results for multiple different parameters, it was unclear in the literature which parameters were most clinically relevant.

Assessing the prognostic value of biomarkers or echocardiographic parameters for such outcomes as the need for transplantation may be biased since all these studies were observational and lacked blinding, and the predictors may have influenced clinical decisions about management or referral for transplantation. Additional research is needed to more fully address the questions posed by KQ 2. Future studies need to evaluate how biomarkers or echocardiography affect diagnostic thinking efficacy and therapeutic efficacy. It has been proposed that a measure that combines a biomarker or biomarkers and echocardiography may be a more effective tool in managing PAH, but research is needed to support this theory. More research needs to be done focusing on response to therapy with increased standardization of duration of followup and medication regimens. A greater body of evidence is needed for novel biomarkers and echocardiographic parameters to effectively assess their usefulness in managing PAH. Future studies should focus on echocardiographic parameters and RHC parameters that are most clinically important.

The evidence for KQ 3 had several limitations. First, we found only a small number of RCTs to analyze. This greatly limited our ability to perform the wide range of meta-analyses on which we had planned, and as such there are gaps in the data. We did not identify any eligible studies that evaluated the comparative effectiveness of calcium channel blockers on intermediate-term and long-term patient outcomes, or that randomized treatment- naïve patients to monotherapy versus combination therapy, or that directly compared two drug classes.

Study populations also were not comparable from study to study, in part because sicker patients are more likely to be receiving prostanoid therapy, so the data on the efficacy of oral therapies may appear to be more favorable because they were studied in patients who were less sick. There is also a paucity of evidence in the published literature to help interpret the clinical significance of the magnitude of effects observed for most outcomes. Recent data on 6MWD, the most commonly assessed outcome measure in the studies analyzed for KQ 3 illustrate this issue. Mathai et al.211 recently estimated the minimal important difference of the 6MWD for patients with PAH to be approximately 33 meters, which is very close to the effect observed for each of the three drug classes we evaluated, as well as the apparent benefit conferred by combination therapy relative to continuation of monotherapy in patients already on monotherapy. Another recent study suggested a threshold of 41.8 m for change in 6MWD to result in a reduction in clinical events.216 These recent findings suggest that there may be some question as to the extent to which the statistically significant improvements in 6MWD associated with treatment in clinical trials is clinically meaningful. The paucity of evidence about minimal important differences applies especially to the intermediate outcomes assessed by right heart catheterization. The evidence base for KQ 3 was also limited by nonstandardized and nonsystematic reporting of adverse events.

Although we did not find evidence for publication bias in a funnel plot of 6MWD outcomes, this does not ensure the absence of selective reporting. Modest but statistically significant effects seen in extant studies might nevertheless result from biases in study design or selective reporting of results. The extent to which the funding source may be related to this is unclear from our data; a majority of treatment trials (68%) were industry funded.

## Research Gaps

The available evidence leaves numerous gaps and areas for potential future research. We used the framework recommended by Robinson et al.217 to identify gaps in evidence and describe why these gaps exist. Results are as follows:

### KQ 1 Screening for PAH

- Patients at elevated risk for PAH, other than systemic sclerosis, have been seldom studied in screening test studies.
  ○ Consider cohort studies of testing for PH among high-risk populations other than those with systemic sclerosis, including patients with HIV, sickle cell anemia or trait portal hypertension, family history of PAH, or catecholaminergic drug use.
  ○ Different populations may have different risks of PAH and different benefits from screening; in studies where heterogeneous populations are included, the effectiveness of screening should be examined according to risk factor.
- Relatively few data exist on screening of asymptomatic patients with a combination of echocardiography and biomarker testing.
  ○ Consider cohort studies that apply echocardiography and biomarker screening in a coordinated or algorithmic way, and studies that verify diagnosis in at least a sample of test-negative patients by RHC or lengthy followup.
  ○ Future tests of the added value of biomarkers should use well-validated echocardiography parameters as a screening test, including estimates of pulmonary artery pressures (sPAP, TG, and TRV) and pulmonary vascular resistance (TRV/VTI_RVOT_).
- Studies of echocardiography for diagnosis of PH have focused on the association of single measures or parameters at a time rather than an integrated diagnostic assessment based on an entire exam and multiple echocardiographic measures or parameters.
  ○ Consider studies that evaluate a global echocardiographic assessment based not only on sPAP but also on right heart chamber size wall thickness and function, estimated PVR, and left heart measures.
  ○ Consider further development of data on the use of echocardiography to measure exercise response to sPAP.
  ○ Consider further development of echocardiographic estimation of mPAP, which would better align with the diagnostic criteria for PAH.
  ○ Consider studies of additional promising measures such as end diastolic pulmonary regurgitation gradient, mean tricuspid regurgitation gradient, and Doppler tissue imaging of the tricuspid annulus.

### KQ 2 Management of PAH

- Echocardiographic- and BNP-guided treatment strategies have not been explicitly tested.
  ○ Consider cohort studies evaluating prognosis as well as treatment trials examining association of baseline echocardiographic parameters and BNP levels to response to treatment.
- Other imaging modalities, such as magnetic resonance imaging, have been little studied as an alternative noninvasive test to assess RV function.
- Cardiopulmonary exercise testing and exercise echocardiography have relatively few data, uncertain clinical utility, and relationship to PH diagnostic criteria.
  ○ Consider validation studies to demonstrate prognostic value particularly for patients with normal resting echocardiography but abnormal exercise echocardiography.

### KQ 3 Pharmacotherapy for PAH

- Relatively few data exist on the efficacy of treating PAH early in the disease course (WHO functional class I-II).
  ○ Improved data on efficacy of early PAH would strengthen linkage to efficacy of screening testing.
  ○ Consider treatment trials in early stage PAH, particularly among patients identified by case finding or screening interventions.
- Relatively few data exist on children with persistent PH or congenital heart disease.
  ○ Consider controlled trials in children.
- Few treatment trials address direct comparison of alternative drug treatment, particularly for PAH patients early in the disease course.
  ○ Consider trials designed to compare clinical alternative treatments to permit more evidence-based treatment selection such as head-to-head treatment comparisons rather than placebo-control or combination versus monotherapy trials.
- The majority of RCTs thus far have not collected adequate surrogate data and have failed to demonstrate therapeutic gain in terms of definitive endpoints.
  ○ Consider including biomarker and imaging techniques with conventional clinical outcomes to improve data on validity and responsiveness of surrogate outcomes.
- Few data are available about differences in response to treatment based on patient characteristics from trials.
  ○ Consider subgroup analysis of treatment efficacy by WHO functional class, underlying etiology, and other patient-level factors.
- Data on the efficacy of combination treatments are limited.
  ○ Consider more combination treatment trials, in particular trials with clear criteria for starting combination therapy and trials in patients who have not failed monotherapy.
- The duration of controlled trial efficacy data are limited.
  ○ Consider, particularly for clinically relevant comparisons (e.g., head-to-head treatment or combo versus monotherapy trials), longer term followup studies that retain randomized group comparisons while assessing long-term efficacy.