# Conclusions

Further research is needed to confirm the single good-quality study suggesting that echocardiography and the biomarker NT-proBNP in combination may be sufficiently accurate to rule out PAH when testing symptomatic patients. In asymptomatic populations, more research is needed to draw conclusions regarding the effectiveness for screening. BNP, RA size, the presence of pericardial effusion and uric acid had prognostic value in patients with PAH, but other echocardiographic parameters and biomarkers either were not predictive or had insufficient data. Although no treatments demonstrate a strong and consistent mortality reduction, many are associated with improved 6MWD and reduced hospitalization rates. Comparisons of different drug combinations are inconclusive regarding a mortality reduction but suggest an improvement in 6MWD compared with continuation of monotherapy.