# Correlation Table for KQ 2

Table G-1 Correlation table for KQ 2 (management of PAH)

Study | Age (Variability) | Timing | Index Tests | Comparators | N | Result | p-value
Andreassen, 2006^1^ | NR for total cohort | Baseline | BNP | Cardiac index | 61 | −0.58 | <0.001
Andreassen, 2006^1^ | NR for total cohort | Baseline | BNP | Functional class | 61 | 0.27 | 0.047
Andreassen, 2006^1^ | NR for total cohort | Baseline | BNP | RHC-mPAP | 61 | 0.47 | <0.001
Andreassen, 2006^1^ | NR for total cohort | Baseline | BNP | RHC-PVR | 61 | 0.66 | <0.001
Andreassen, 2006^1^ | NR for total cohort | Baseline | BNP | RHC-PVR | 17 | 0.55 | 0.041
Andreassen, 2006^1^ | NR for total cohort | Baseline | BNP | RHC-sPAP | 61 | −0.29 | 0.028
Andreassen, 2006^1^ | NR for total cohort | Baseline | BNP | Right atrial pressure | 61 | 0.47 | <0.001
Bendayan, 2002^2^ | Mean 54.9 (Range 16 to 80) | Baseline | Uric acid | 6MWD (absolute) | 29 | −0.35 | 0.03
Bendayan, 2002^2^ | Mean 54.9 (Range 16 to 80) | Baseline | Uric acid | Functional class | 29 | 0.66 | 0.001
Bendayan, 2002^2^ | Mean 54.9 (Range 16 to 80) | Baseline | Uric acid | Mortality | 29 | 0.66 | 0.001
Bendayan, 2002^2^ | Mean 54.9 (Range 16 to 80) | Baseline | Uric acid | RHC-CO | 29 | 0.06 | 0.72
Bendayan, 2002^2^ | Mean 54.9 (Range 16 to 80) | Baseline | Uric acid | RHC-mPAP | 29 | 0.19 | 0.17
Bernus, 2009^3^ | Median 9.3 (Range 5.2 to 14.2) | Baseline | BNP | Cardiac index | 52 | −0.08 | NS
Bernus, 2009^3^ | Median 9.3 (Range 5.2 to 14.2) | Baseline | BNP | Peak TRV | 47 | 0.23 | NS
Bernus, 2009^3^ | Median 9.3 (Range 5.2 to 14.2) | Baseline | BNP | PCWP | 56 | 0.26 | <0.05
Bernus, 2009^3^ | Median 9.3 (Range 5.2 to 14.2) | Baseline | BNP | RHC-mPAP | 57 | 0.16 | NS
Bernus, 2009^3^ | Median 9.3 (Range 5.2 to 14.2) | Baseline | BNP | RHC-PVR | 56 | 0.06 | NS
Bernus, 2009^3^ | Median 9.3 (Range 5.2 to 14.2) | Baseline | BNP | Right atrial pressure | 56 | 0.34 | p<0.05
Bernus, 2009^3^ | Median 9.3 (Range 5.2 to 14.2) | Baseline | BNP | RV size | 42 | 0.23 | NS
Borges, 2006^4^ | Mean 56.4 (SD 11) | Baseline | RIMP/MPI/Tei Index | 6MWD (absolute) | 37 | −0.73 | 0.661
Borges, 2006^4^ | Mean 56.4 (SD 11) | Baseline | RIMP/MPI/Tei Index | RHC-PVR | 37 | 0.172 | 0.47
Borges, 2006^4^ | Mean 56.4 (SD 11) | Baseline | TAPSE | 6MWD (absolute) | 37 | 0.36 | 0.028
Borges, 2006^4^ | Mean 56.4 (SD 11) | Baseline | TAPSE | RHC-PVR | 37 | −0.072 | 0.53
Campana, 2004^5^ | Mean 50 (SD 11) | Baseline | BNP | Cardiac index | 22 | r^2^=0.2 (negative correlation)
Campana, 2004^5^ | Mean 50 (SD 11) | Baseline | BNP | RHC-mPAP | 22 | r^2^=0.1
Campana, 2004^5^ | Mean 50 (SD 11) | Baseline | BNP | Right atrial pressure | 22 | r^2^=0.09
Campana, 2004^5^ | Mean 50 (SD 11) | Baseline | BNP | RVEF | 22 | r^2^=0.46 (negative correlation)
Campana, 2004^5^ | Mean 50 (SD 11) | Baseline | BNP | TAPSE | 22 | r^2^=0.005
Cella, 2009^6^ | Mean 53.8 (SD 13.1) | 1 year | Change in RVSP | 6MWD (change) | 18 | R2=0.5355 | 0.0006
Chin, 2007^7^ | NR | Baseline | BNP | 6MWD (absolute) | 27 | −0.59 | 0.04
Chin, 2007^7^ | NR | Baseline | BNP | PCWP | 27 | 0.32 | 0.10
Chin, 2007^7^ | NR | Baseline | BNP | RHC-CO | 27 | −0.25 | 0.19
Chin, 2007^7^ | NR | Baseline | BNP | RHC-mPAP | 27 | 0.29 | 0.14
Chin, 2007^7^ | NR | Baseline | BNP | RHC-PVR | 27 | 0.28 | 0.15
Chin, 2007^7^ | NR | Baseline | BNP | Right atrial pressure | 27 | 0.66 | <0.001
Dyer, 2006^8^ | Mean 9.6 (SD 4.8) | Baseline | RIMP/MPI/Tei Index | RHC-mPAP | 12 | 0.94 | <0.001
Dyer, 2006^8^ | Mean 9.6 (SD 4.8) | Intermediate | RIMP/MPI/Tei Index | RHC-mPAP | 12 | 0.90 | <0.001
Fahmy Elnoamany, 2007^9^ | Mean 55.3 (SD 10.39) | Baseline | Endothelin-1 | RHC-sPAP | 53 | 0.94 | <0.001
Fahmy Elnoamany, 2007^9^ | Mean 55.3 (SD 10.39) | Baseline | sPAP | RHC-sPAP | 53 | 0.92 | <0.001
Fijalkowska, 2006^10^ | Mean 41 (SD 15.1) | Baseline | BNP | 6MWD (absolute) | 55 | −0.60 | <0.001
Fijalkowska, 2006^10^ | Mean 41 (SD 15.1) | Baseline | BNP | Cardiac index | 55 | −0.65 | <0.001
Fijalkowska, 2006^10^ | Mean 41 (SD 15.1) | Baseline | BNP | Functional class | 55 | 0.45 | <0.001
Fijalkowska, 2006^10^ | Mean 41 (SD 15.1) | Baseline | BNP | Peak TRV | 55 | 0.08 | NS
Fijalkowska, 2006^10^ | Mean 41 (SD 15.1) | Baseline | BNP | RHC-mPAP | 55 | 0.21 | NS
Fijalkowska, 2006^10^ | Mean 41 (SD 15.1) | Baseline | BNP | RHC-PVR | 55 | 0.43 | <0.001
Fijalkowska, 2006^10^ | Mean 41 (SD 15.1) | Baseline | BNP | Right atrial pressure | 55 | 0.45 | <0.001
Forfia, 2006^11^ | Mean 55 (SD 15) | Baseline | TAPSE | RHC-PVR | 63 | −0.52 | <0.0001
Friedberg, 2006^12^ | NR | Baseline | mPAP | RHC-mPAP | 17 | 0.85 | <0.0001
Friedberg, 2006^12^ | NR | Baseline | mPAP | RHC-mPAP | 17 | 0.85 | <0.0001
Friedberg, 2006^12^ | NR | Baseline | sPAP | RHC-sPAP | 17 | 0.88 | <0.0001
Friedberg, 2006^12^ | NR | Baseline | sPAP | RHC-sPAP | 17 | 0.88 | <0.0001
Gan, 2006^13^ | Mean 48 (Range 21 to 80) | Baseline | BNP | 6MWD (absolute) | 30 | −0.51 | 0.008
Gan, 2006^13^ | Mean 48 (Range 21 to 80) | Baseline | BNP | Cardiac index | 30 | −0.45 | 0.019
Gan, 2006^13^ | Mean 48 (Range 21 to 80) | Baseline | BNP | RHC-mPAP | 30 | 0.28 | 0.143
Gan, 2006^13^ | Mean 48 (Range 21 to 80) | Baseline | BNP | RHC-PVR | 30 | 0.30 | 0.122
Gan, 2006^13^ | Mean 48 (Range 21 to 80) | Baseline | BNP | Right atrial pressure | 30 | 0.49 | 0.008
Ghofrani, 2002^14^ | Mean 48.3 (SEM 3.7) | Baseline | ANP | RHC-PVR | 20 | 0.66 | <0.0001
Ghofrani, 2002^14^ | Mean 48.3 (SEM 3.7) | Baseline | cGMP | RHC-PVR | 36 | 0.139 | NS
Goto, 2010^15^ | Mean 64.07 (SD 12.28) | Baseline | BNP | RHC-mPAP | 46 | 0.508 | 0.044
Goto, 2010^15^ | Mean 64.07 (SD 12.28) | Baseline | sPAP | RHC-sPAP | 46 | 0.505 | <0.01
Grubstein, 2008^16^ | Mean 52 (Range 20 to 80) | Baseline | sPAP | RHC-sPAP | 38 | 0.6 | 0.001
Haddad, 2009^17^ | Mean 49 (SD 11) | Baseline | mPAP | RHC-mPAP | 51 | 0.94 | 0.90–0.97
Haddad, 2009^17^ | Mean 49 (SD 11) | Baseline | sPAP | RHC-sPAP | 48 | 0.97 | 0.94–0.98
Heresi, 2010^18^ | Mean 44 (SD 14) | Baseline | BNP | 6MWD (absolute) | 40 | −0.58 | <0.001
Heresi, 2010^18^ | Mean 44 (SD 14) | Baseline | BNP | Cardiac index | 40 | −0.31 | 0.07
Heresi, 2010^18^ | Mean 44 (SD 14) | Baseline | BNP | RHC-mPAP | 40 | 0.26 | 0.10
Heresi, 2010^18^ | Mean 44 (SD 14) | Baseline | BNP | RHC-PVR | 40 | 0.15 | 0.36
Heresi, 2010^18^ | Mean 44 (SD 14) | Baseline | BNP | Right atrial pressure | 40 | 0.49 | 0.001
Heresi, 2012^19^ | Mean 47 (SD 13) | Baseline | cTnI (detectable) | 6MWD (absolute) | 68 | −0.29 | 0.020
Heresi, 2012^19^ | Mean 47 (SD 13) | Baseline | cTnI (detectable) | Functional class | 68 | 0.36 | 0.002
Heresi, 2012^19^ | Mean 47 (SD 13) | Baseline | cTnI (detectable) | BNP | 68 | 0.45 | 0.001
Heresi, 2012^19^ | Mean 47 (SD 13) | Baseline | cTnI (detectable) | RA size | 68 | 0.36 | 0.010
Hinderliter, 1997^20^ | NR for total cohort | Baseline | FAC | 6MWD (absolute) | 75 | 0.08
Hinderliter, 1997^20^ | NR for total cohort | Baseline | FAC | Cardiac index | 75 | −0.01
Hinderliter, 1997^20^ | NR for total cohort | Baseline | FAC | RHC-mPAP | 75 | −0.37 | <0.01
Hinderliter, 1997^20^ | NR for total cohort | Baseline | FAC | Right atrial pressure | 75 | −0.01
Hinderliter, 1997^20^ | NR for total cohort | Baseline | Pericardial effusion | 6MWD (absolute) | 75 | −0.50 | <0.01
Hinderliter, 1997^20^ | NR for total cohort | Baseline | Pericardial effusion | Cardiac index | 75 | −0.40 | <0.001
Hinderliter, 1997^20^ | NR for total cohort | Baseline | Pericardial effusion | RHC-mPAP | 75 | 0.22
Hinderliter, 1997^20^ | NR for total cohort | Baseline | Pericardial effusion | Right atrial pressure | 75 | 0.50 | <0.001
Hinderliter, 1997^20^ | NR for total cohort | Baseline | RV size | 6MWD (absolute) | 75 | −0.24 | <0.05
Hinderliter, 1997^20^ | NR for total cohort | Baseline | RV size | Cardiac index | 75 | −0.16
Hinderliter, 1997^20^ | NR for total cohort | Baseline | RV size | RHC-mPAP | 75 | 0.25
Hinderliter, 1997^20^ | NR for total cohort | Baseline | RV size | Right atrial pressure | 75 | 0.45 | <0.001
Hinderliter, 1997^20^ | NR for total cohort | Baseline | sPAP | RHC-sPAP | 75 | 0.57 | <0.001
Homma, 2001^21^ | Mean 45.0 (SD 10.6) | Baseline | sPAP | RHC-sPAP | 8 | r^2^=0.11
Leuchte, 2005^22^ | Mean 46.93 (SEM 2.8) | Mean followup 12.6 ± 1.5 months | Change in BNP | Change in 6MWD | 30 | −0.74 | <0.001
Leuchte, 2005^22^ | Mean 46.93 (SEM 2.8) | Mean followup 12.6 ± 1.5 months | Change in BNP | Change in cardiac index | 30 | −0.49 | <0.01
Leuchte, 2005^22^ | Mean 46.93 (SEM 2.8) | Mean followup 12.6 ± 1.5 months | Change in BNP | Change in RHC-CO | 30 | −0.48 | <0.01
Leuchte, 2005^22^ | Mean 46.93 (SEM 2.8) | Mean followup 12.6 ± 1.5 months | Change in BNP | Change in RHC-mPAP | 30 | 0.54 | <0.01
Leuchte, 2005^22^ | Mean 46.93 (SEM 2.8) | Mean followup 12.6 ± 1.5 months | Change in BNP | Change in RHC-PVR | 30 | 0.55 | <0.01
Leuchte, 2005^22^ | Mean 46.93 (SEM 2.8) | Mean followup 12.6 ± 1.5 months | Change in BNP | Change in right atrial pressure | 30 | 0.78 | <0.001
Machado, 2006^23^ | NR for total cohort | Baseline | BNP | 6MWD (absolute) | 34 | −0.54 | 0.001
Machado, 2006^23^ | NR for total cohort | Baseline | BNP | PCWP | 37 | 0.30 | 0.07
Machado, 2006^23^ | NR for total cohort | Baseline | BNP | RA size | 211 | 0.21 | 0.002
Machado, 2006^23^ | NR for total cohort | Baseline | BNP | RHC-CO | 37 | −0.43 | 0.006
Machado, 2006^23^ | NR for total cohort | Baseline | BNP | RHC-dPAP | 37 | 0.37 | 0.02
Machado, 2006^23^ | NR for total cohort | Baseline | BNP | RHC-mPAP | 37 | 0.43 | 0.006
Machado, 2006^23^ | NR for total cohort | Baseline | BNP | RHC-PVR | 37 | 0.51 | 0.001
Machado, 2006^23^ | NR for total cohort | Baseline | BNP | RHC-sPAP | 37 | 0.59
Machado, 2004^24^ | NR for total cohort | Baseline | Nitric oxide | RHC-mPAP | 12 | 0.56 | 0.054
Machado, 2004^24^ | NR for total cohort | Baseline | sPAP | RHC-sPAP | 17 | 0.794 | <0.001
Montani, 2007^25^ | Mean 43.8 (Range 33.8–56.6) | Baseline | Endothelin-1 | Cardiac index | 33 | −0.47 | <0.008
Montani, 2007^25^ | Mean 43.8 (Range 33.8–56.6) | Baseline | Endothelin-1 | RHC-PVR | 33 | 0.55 | <0.05
Montani, 2007^25^ | Mean 43.8 (Range 33.8–56.6) | Baseline | Endothelin-1 | Right atrial pressure | 33 | 0.46 | 0.01
Morishita, 2009^26^ | Mean 32.6 (Range 15–49) | Baseline | Pericardial effusion | Functional class | 7 | 0.34 | <0.05
Morishita, 2009^26^ | Mean 32.6 (Range 15–49) | Baseline | RA size | Functional class | 7 | 0.33 | NS
Mukerjee, 2003^27^ | Mean 57 (Range 34–80) | Baseline | BNP | RHC-mPAP | 23 | r^2^=0.28 | <0.05
Mukerjee, 2003^27^ | Mean 57 (Range 34–80) | Baseline | BNP | RHC-PVR | 23 | r^2^=0.24 | <0.05
Nagaya, 2000^28^ | NR for total cohort | Baseline | ANP | PCWP | 60 | 0.22 | NS
Nagaya, 2000^28^ | NR for total cohort | Baseline | ANP | RHC-CO | 60 | −0.49 | <0.001
Nagaya, 2000^28^ | NR for total cohort | Baseline | ANP | RHC-mPAP | 60 | 0.42 | <0.001
Nagaya, 2000^28^ | NR for total cohort | Baseline | ANP | Right atrial pressure | 60 | 0.55 | <0.001
Nagaya, 2000^28^ | NR for total cohort | Baseline | BNP | PCWP | 60 | 0.16
Nagaya, 2000^28^ | NR for total cohort | Baseline | BNP | RHC-CO | 60 | −0.51 | <0.001
Nagaya, 2000^28^ | NR for total cohort | Baseline | BNP | RHC-mPAP | 60 | 0.42
Nagaya, 2000^28^ | NR for total cohort | Baseline | BNP | RHC-mPAP | 60 | 0.43 | <0.05
Nagaya, 2000^28^ | NR for total cohort | Baseline | BNP | RHC-PVR | 60 | 0.59 | <0.001
Nagaya, 2000^28^ | NR for total cohort | Baseline | BNP | Right atrial pressure | 60 | 0.55 | <0.001
Nath, 2005^29^ | Mean 46 (SD 11) | Long-term >1 year | Peak TRV | Functional class | 20 | 0.26 | 0.29
Nath, 2005^29^ | Mean 46 (SD 11) | Long-term >1 year | Peak TRV | Functional class | 20 | 0.23 | 0.33
Nath, 2005^29^ | Mean 46 (SD 11) | Long-term >1 year | Peak TRV | Functional class | 20 | 0.38 | 0.10
Nickel, 2008^30^ | Mean 47.6 (SD 15.8) | Baseline | BNP | 6MWD (absolute) | 139 | −0.217 | 0.028
Nickel, 2008^30^ | Mean 47.6 (SD 15.8) | Baseline | BNP | Cardiac index | 139 | −0.378 | 0.001
Nickel, 2008^30^ | Mean 47.6 (SD 15.8) | Baseline | BNP | PCWP | 139 | −0.027 | 0.9
Nickel, 2008^30^ | Mean 47.6 (SD 15.8) | Baseline | BNP | RHC-PVR | 139 | 0.321 | 0.006
Nickel, 2008^30^ | Mean 47.6 (SD 15.8) | Baseline | BNP | Right atrial pressure | 139 | 0.283 | 0.008
Pyxaras, 2011^31^ | Mean 55 (SD 19) | Baseline | sPAP | RHC-sPAP | 60 | 0.457 | 0.002
Pyxaras, 2011^31^ | Mean 55 (SD 19) | Baseline | mPAP | RHC-mPAP | 60 | 0.451 | 0.006
Souza, 2007^32^ | Mean 37 (SEM 2) | Baseline | BNP | 6MWD (absolute) | 42 | −0.31 | 0.052
Souza, 2007^32^ | Mean 37 (SEM 2) | Baseline | BNP | Cardiac index | 42 | −0.70 | <0.001
Souza, 2007^32^ | Mean 37 (SEM 2) | Baseline | BNP | Functional class | 42 | 0.81 | <0.001
Souza, 2007^32^ | Mean 37 (SEM 2) | Baseline | BNP | RHC-mPAP | 42 | 0.58 | <0.001
Souza, 2007^32^ | Mean 37 (SEM 2) | Baseline | BNP | RHC-PVR | 42 | 0.80 | <0.001
Souza, 2007^32^ | Mean 37 (SEM 2) | Baseline | BNP | Right atrial pressure | 42 | 0.68 | 0.004
Takatsuki, 2012^33^ | Median 10 (Range 5–15) | Baseline | BNP | 6MWD (absolute) | 41 | −0.32 | 0.04
Takatsuki, 2012^33^ | Median 10 (Range 5–15) | Baseline | BNP | RHC-mPAP | 47 | 0.34 | 0.02
Takatsuki, 2012^33^ | Median 10 (Range 5–15) | Baseline | BNP | Right atrial pressure | 45 | 0.48 | <0.01
Takatsuki, 2012^33^ | Median 10 (Range 5–15) | Baseline | BNP | RHC-PVRi | 46 | 0.30 | 0.04
Takatsuki, 2012^33^ | Median 10 (Range 5–15) | Baseline | BNP | RHC-CI | 41 | −0.22 | 0.16
Takatsuki, 2012^33^ | Median 10 (Range 5–15) | Baseline | BNP | TRJv | 69 | 0.36 | <0.01
Takatsuki, 2012^33^ | Median 10 (Range 5–15) | Baseline | BNP | WHO FC | 36 | 0.32 | 0.06
Takatsuki, 2012^33^ | Median 10 (Range 5–15) | Baseline | NT-proBNP | 6MWD (absolute) | 41 | −0.49 | <0.01
Takatsuki, 2012^33^ | Median 10 (Range 5–15) | Baseline | NT-proBNP | RHC-mPAP | 47 | 0.28 | 0.06
Takatsuki, 2012^33^ | Median 10 (Range 5–15) | Baseline | NT-proBNP | Right atrial pressure | 45 | 0.48 | <0.01
Takatsuki, 2012^33^ | Median 10 (Range 5–15) | Baseline | NT-proBNP | RHC-PVRi | 46 | 0.23 | 0.12
Takatsuki, 2012^33^ | Median 10 (Range 5–15) | Baseline | NT-proBNP | RHC-CI | 41 | −0.01 | 0.93
Takatsuki, 2012^33^ | Median 10 (Range 5–15) | Baseline | NT-proBNP | TRJv | 69 | 0.41 | <0.01
Takatsuki, 2012^33^ | Median 10 (Range 5–15) | Baseline | NT-proBNP | WHO FC | 36 | 0.35 | 0.04
Utsunomiya, 2009^34^ | Mean 46 (SD 13) | Baseline | RA size | Right atrial pressure | 50 | 0.31 | 0.03
Van Albada, 2008^35^ | Median 7.0 (Range 0.1–17.3) | Baseline | BNP | 6MWD (absolute) | 29 | −0.527 | <0.001
Van Albada, 2008^35^ | Median 7.0 (Range 0.1–17.3) | Long-term >1 year | BNP | 6MWD (change) | 20 | −0.63 | 0.04
Van Albada, 2008^35^ | Median 7.0 (Range 0.1–17.3) | Baseline | BNP | Functional class | 29 | 0.34 | 0.04
Van Albada, 2008^35^ | Median 7.0 (Range 0.1–17.3) | Long-term >1 year | BNP | Functional class | 20 | 0.72 | 0.02
Van Albada, 2008^35^ | Median 7.0 (Range 0.1–17.3) | Long-term >1 year | BNP | Mortality | 29 | 9.93 | 0.002
Van Albada, 2008^35^ | Median 7.0 (Range 0.1–17.3) | Baseline | Uric acid | Cardiac index | 16 | −0.65 | 0.007
Van Albada, 2008^35^ | Median 7.0 (Range 0.1–17.3) | Long-term >1 year | Uric acid | Mortality | 29 | 5.93 | 0.015
Van Albada, 2008^35^ | Median 7.0 (Range 0.1–17.3) | Baseline | Uric acid | RHC-mPAP | 16 | 0.63 | 0.01
Van Albada, 2008^35^ | Median 7.0 (Range 0.1–17.3) | Baseline | Uric acid | RHC-PVR | 16 | 0.71 | 0.03
Vizza, 2012^36^ | Mean 53 (SD 17) | Baseline | ET-1 | WHO FC | 44 | 0.35 | 0.02
Vizza, 2012^36^ | Mean 53 (SD 17) | Baseline | ET-1 | BNP | 44 | 0.51 | 0.001
Vizza, 2012^36^ | Mean 53 (SD 17) | Baseline | ET-1 | RHC-mPAP | 44 | 0.38 | 0.01
Vizza, 2012^36^ | Mean 53 (SD 17) | Baseline | ET-1 | RHC-CI | 44 | −0.43 | 0.004
Vizza, 2012^36^ | Mean 53 (SD 17) | Baseline | ET-1 | RHC-PVR | 44 | 0.48 | 0.001
Voelkel, 2000^37^ | NR for total cohort | Baseline | Uric acid | RHC-mPAP | 191 | 0.41 | <0.0001
Voelkel, 2000^37^ | NR for total cohort | Baseline | Uric acid | Right atrial pressure | 191 | 0.486 | <0.0001
Williams, 2006^38^ | Mean 60 (SD 11) | Baseline | BNP | Cardiac index | 68 | −0.5 | <0.0001
Williams, 2006^38^ | Mean 60 (SD 11) | Baseline | BNP | RHC-mPAP | 68 | 0.62 | <0.0001
Williams, 2006^38^ | Mean 60 (SD 11) | Baseline | BNP | RHC-PVR | 68 | 0.81 | <0.0001
Williams, 2006^38^ | Mean 60 (SD 11) | Baseline | BNP | Right atrial pressure | 68 | 0.53 | <0.0001
Zafrir, 2007^39^ | Mean 51 (SD 14.7) | Baseline | RA size | 6MWD (absolute) | 29 | −0.42 | 0.02
Zafrir, 2007^39^ | Mean 51 (SD 14.7) | Baseline | | Functional class | 29 | 0.39 | 0.04
Zafrir, 2007^39^ | Mean 51 (SD 14.7) | Baseline | RIMP/MPI/Tei Index | 6MWD (absolute) | 29 | −0.25 | 0.18
Zafrir, 2007^39^ | Mean 51 (SD 14.7) | Baseline | RVEF | Functional class | 29 | −0.45 | 0.019

Abbreviations: 6MWD=6-minute walk distance; ANP=A-type natriuretic peptide; BNP=B-type natriuretic peptide ; CO=cardiac output; CVD=collagen vascular disease; FAC=fractional area change; mPAP=mean pulmonary artery pressure; MPI=myocardial performance index; NR=not reported; PCWP=pulmonary capillary wedge pressure; PVR=pulmonary vascular resistance; RA=right atrium; RIMP=right index of myocardial performance; RV=right ventricle; RVEF=right ventricular ejection fraction; SD=standard deviation; SEM=standard error of the mean; sPAP=systolic pulmonary artery pressure; TAPSE=tricuspid annular plane systolic excursion; TRV=tricuspid regurgitant jet velocity

## References Cited in Appendix G

1 Andreassen AK, Wergeland R, Simonsen S, et al. N-terminal pro-B-type natriuretic peptide as an indicator of disease severity in a heterogeneous group of patients with chronic precapillary pulmonary hypertension. Am J Cardiol. 2006;98(4):525-9. [pmid: 16893710].
2 Bendayan D, Shitrit D, Ygla M, et al. Hyperuricemia as a prognostic factor in pulmonary arterial hypertension. Respir Med. 2003;97(2):130-3. [pmid: 12587962].
3 Bernus A, Wagner BD, Accurso F, et al. Brain natriuretic peptide levels in managing pediatric patients with pulmonary arterial hypertension. Chest. 2009;135(3):745-51. [pmid: 18849405].
4 Borges AC, Knebel F, Eddicks S, et al. Right ventricular function assessed by two-dimensional strain and tissue Doppler echocardiography in patients with pulmonary arterial hypertension and effect of vasodilator therapy. Am J Cardiol. 2006;98(4):530-4. [pmid: 16893711].
5 Campana C, Pasotti M, Monti L, et al. The evaluation of right ventricular performance in different clinical models of heart failure. Eur Heart J Suppl. 2004;6(6):F61-F67.
6 Cella G, Vianello F, Cozzi F, et al. Effect of bosentan on plasma markers of endothelial cell activity in patients with secondary pulmonary hypertension related to connective tissue diseases. J Rheumatol. 2009;36(4):760-7. [pmid: 19208592].
7 Chin KM, Channick RN, Kim NH, et al. Central venous blood oxygen saturation monitoring in patients with chronic pulmonary arterial hypertension treated with continuous IV epoprostenol: correlation with measurements of hemodynamics and plasma brain natriuretic peptide levels. Chest. 2007;132(3):786-92. [pmid: 17646224].
8 Dyer KL, Pauliks LB, Das B, et al. Use of myocardial performance index in pediatric patients with idiopathic pulmonary arterial hypertension. J Am Soc Echocardiogr. 2006;19(1):21-7. [pmid: 16423665].
9 Fahmy Elnoamany M, Abdelraouf Dawood A. Right ventricular myocardial isovolumic relaxation time as novel method for evaluation of pulmonary hypertension: correlation with endothelin-1 levels. J Am Soc Echocardiogr. 2007;20(5):462-9. [pmid: 17484984].
10 Fijalkowska A, Kurzyna M, Torbicki A, et al. Serum N-terminal brain natriuretic peptide as a prognostic parameter in patients with pulmonary hypertension. Chest. 2006;129(5):1313-21. [pmid: 16685024].
11 Forfia PR, Fisher MR, Mathai SC, et al. Tricuspid annular displacement predicts survival in pulmonary hypertension. Am J Respir Crit Care Med. 2006;174(9):1034-41. [pmid: 16888289].
12 Friedberg MK, Feinstein JA, Rosenthal DN. A novel echocardiographic Doppler method for estimation of pulmonary arterial pressures. J Am Soc Echocardiogr. 2006;19(5):559-62. [pmid: 16644441].
13 Gan CT, McCann GP, Marcus JT, et al. NT-proBNP reflects right ventricular structure and function in pulmonary hypertension. Eur Respir J. 2006;28(6):1190-4. [pmid: 16971413].
14 Ghofrani HA, Wiedemann R, Rose F, et al. Lung cGMP release subsequent to NO inhalation in pulmonary hypertension: responders versus nonresponders. Eur Respir J. 2002;19(4):664-71. [pmid: 11998996].
15 Goto K, Arai M, Watanabe A, et al. Utility of echocardiography versus BNP level for the prediction of pulmonary arterial pressure in patients with pulmonary arterial hypertension. Int Heart J. 2010;51(5):343-7. [pmid: 20966607].
16 Grubstein A, Benjaminov O, Dayan DB, et al. Computed tomography angiography in pulmonary hypertension. Isr Med Assoc J. 2008;10(2):117-20. [pmid: 18432023].
17 Haddad F, Zamanian R, Beraud AS, et al. A novel non-invasive method of estimating pulmonary vascular resistance in patients with pulmonary arterial hypertension. J Am Soc Echocardiogr. 2009;22(5):523-9. [pmid: 19307098].
18 Heresi GA, Aytekin M, Newman J, et al. CXC-chemokine ligand 10 in idiopathic pulmonary arterial hypertension: marker of improved survival. Lung. 2010;188(3):191-7. [pmid: 20186422].
19 Heresi GA, Tang WH, Aytekin M, et al. Sensitive cardiac troponin I predicts poor outcomes in pulmonary arterial hypertension. Eur Respir J. 2012;39(4):939-44. [pmid: 21885398].
20 Hinderliter AL, Willis PWt, Barst RJ, et al. Effects of long-term infusion of prostacyclin (epoprostenol) on echocardiographic measures of right ventricular structure and function in primary pulmonary hypertension. Primary Pulmonary Hypertension Study Group Circulation. 1997;95(6):1479-86. [pmid: 9118516].
21 Homma A, Anzueto A, Peters JI, et al. Pulmonary artery systolic pressures estimated by echocardiogram vs cardiac catheterization in patients awaiting lung transplantation. J Heart Lung Transplant. 2001;20(8):833-9. [pmid: 11502405].
22 Leuchte HH, Holzapfel M, Baumgartner RA, et al. Characterization of brain natriuretic peptide in long-term follow-up of pulmonary arterial hypertension. Chest. 2005;128(4):2368-74. [pmid: 16236896].
23 Machado RF, Anthi A, Steinberg MH, et al. N-terminal pro-brain natriuretic peptide levels and risk of death in sickle cell disease. JAMA. 2006;296(3):310-8. [pmid: 16849664].
24 Machado RF, Londhe Nerkar MV, Dweik RA, et al. Nitric oxide and pulmonary arterial pressures in pulmonary hypertension. Free Radic Biol Med. 2004;37(7):1010-7. [pmid: 15336317].
25 Montani D, Souza R, Binkert C, et al. Endothelin-1/endothelin-3 ratio: a potential prognostic factor of pulmonary arterial hypertension. Chest. 2007;131(1):101-8. [pmid: 17218562].
26 Morishita T, Miyaji K, Akao I, et al. The ratio of the atrial areas reflects the clinical status of patients with pulmonary arterial hypertension. J Med Ultrason. 2009;36(4):201-206.
27 Mukerjee D, Yap LB, Holmes AM, et al. Significance of plasma N-terminal pro-brain natriuretic peptide in patients with systemic sclerosis-related pulmonary arterial hypertension. Respir Med. 2003;97(11):1230-6. [pmid: 14635979].
28 Nagaya N, Nishikimi T, Uematsu M, et al. Plasma brain natriuretic peptide as a prognostic indicator in patients with primary pulmonary hypertension. Circulation. 2000;102(8):865-70. [pmid: 10952954].
29 Nath J, Demarco T, Hourigan L, et al. Correlation between right ventricular indices and clinical improvement in epoprostenol treated pulmonary hypertension patients. Echocardiography. 2005;22(5):374-9. [pmid: 15901287].
30 Nickel N, Kempf T, Tapken H, et al. Growth differentiation factor-15 in idiopathic pulmonary arterial hypertension. Am J Respir Crit Care Med. 2008;178(5):534-41. [pmid: 18565955].
31 Pyxaras SA, Pinamonti B, Barbati G, et al. Echocardiographic evaluation of systolic and mean pulmonary artery pressure in the follow-up of patients with pulmonary hypertension. Eur J Echocardiogr. 2011;12(9):696-701. [pmid: 21821609].
32 Souza R, Jardim C, Julio Cesar, Fernandes C, et al. NT-proBNP as a tool to stratify disease severity in pulmonary arterial hypertension. Respir Med. 2007;101(1):69-75. [pmid: 16781131].
33 Takatsuki S, Wagner BD, Ivy DD. B-type Natriuretic Peptide and Amino-terminal Pro-B-type Natriuretic Peptide in Pediatric Patients with Pulmonary Arterial Hypertension. Congenital Heart Disease. 2012;7(3):259-267. [pmid: 22325151].
34 Utsunomiya H, Nakatani S, Nishihira M, et al. Value of estimated right ventricular filling pressure in predicting cardiac events in chronic pulmonary arterial hypertension. J Am Soc Echocardiogr. 2009;22(12):1368-74. [pmid: 19944957].
35 Van Albada ME, Loot FG, Fokkema R, et al. Biological serum markers in the management of pediatric pulmonary arterial hypertension. Pediatr Res. 2008;63(3):321-7. [pmid: 18287971].
36 Vizza CD, Letizia C, Badagliacca R, et al. Relationship between baseline ET-1 plasma levels and outcome in patients with idiopathic pulmonary hypertension treated with bosentan. Int J Cardiol. 2012. [pmid: 22265324].
37 Voelkel MA, Wynne KM, Badesch DB, et al. Hyperuricemia in severe pulmonary hypertension. Chest. 2000;117(1):19-24. [pmid: 10631193].
38 Williams MH, Handler CE, Akram R, et al. Role of N-terminal brain natriuretic peptide (N-TproBNP) in scleroderma-associated pulmonary arterial hypertension. Eur Heart J. 2006;27(12):1485-94. [pmid: 16682379].
39 Zafrir N, Zingerman B, Solodky A, et al. Use of noninvasive tools in primary pulmonary hypertension to assess the correlation of right ventricular function with functional capacity and to predict outcome. Int J Cardiovasc Imaging. 2007;23(2):209-15. [pmid: 16972146].