# List of Excluded Studies

All studies listed below were reviewed in their full-text version and excluded for the reason shown in italics. Reasons for exclusion signify only the usefulness of the articles for this study and are not intended as criticisms of the articles.

Abbas AE, Fortuin FD, Schiller NB, et al. Echocardiographic determination of mean pulmonary artery pressure. Am J Cardiol. 2003;92(11):1373-6. Exclude - No comparisons of interest. [pmid: 14636929].
Abdelwahed A, Klada E, Vaghasia P, et al. Cardiac-MRI derived index to diagnose pulmonary Hypertension. Chest. 2011;140(4). Exclude - Not a full publication.
Abdul-Salam VB, Paul GA, Ali JO, et al. Identification of plasma protein biomarkers associated with idiopathic pulmonary arterial hypertension. Proteomics. 2006;6(7):2286-94. Exclude - No comparisons of interest. [pmid: 16493708].
Abman SH. Pulmonary hypertension in older children: new approaches and therapies. Paediatr Respir Rev. Suppl 1. 2006;7:S177-9. Exclude - Background Other. [pmid: 16798555].
Acikel M, Yilmaz M, Gurlertop Y, et al. Evaluation of left ventricular diastolic function by doppler echocardiography and tissue doppler imaging in chronic cor pulmonale. Turk Kardiyoloji Dernegi Arsivi. 2003;31(7):384-391. Exclude - not available in English.
Acosta Colman MI, Avila Pedretti G, Acosta ME, et al. Can we predict the severity of pulmonary hypertension in patients with scleroderma?. Reumatologia Clinica. 2012. Exclude - Not a full publication.
Adatia I, Beghetti M. Early postoperative care of patients with pulmonary hypertension associated with congenital cardiac disease. Cardiol Young. 2009;19(4):315-9. Exclude - Not a full publication. [pmid: 19493364].
Adnot S, Raffestin B, Eddahibi S. Nitric oxide in the pulmonary circulation. Monaldi Arch Chest Dis. 1996;51(6):519-27. Exclude - Does not include intervention of interest. [pmid: 9046167].
Adriaenssens T, Delcroix M, Van Deyk K, et al. Advanced therapy may delay the need for transplantation in patients with the Eisenmenger syndrome. Eur Heart J. 2006;27(12):1472-7. Exclude - No comparisons of interest. [pmid: 16707548].
Aduen JF, Castello R, Daniels JT, et al. Accuracy and precision of three echocardiographic methods for estimating mean pulmonary artery pressure. Chest. 2011;139(2):347-52. Exclude - Does not include intervention of interest. [pmid: 20651021].
Aessopos A, Farmakis D, Deftereos S, et al. Cardiovascular effects of splenomegaly and splenectomy in beta-thalassemia. Ann Hematol. 2005;84(6):353-7. Exclude - Does not include intervention of interest. [pmid: 15711802].
Aessopos A, Farmakis D, Deftereos S, et al. Thalassemia heart disease: a comparative evaluation of thalassemia major and thalassemia intermedia. Chest. 2005;127(5):1523-30. Exclude - Does not include intervention of interest. [pmid: 15888823].
Aessopos A, Farmakis D, Hatziliami A, et al. Cardiac status in well-treated patients with thalassemia major. Eur J Haematol. 2004;73(5):359-66. Exclude - Does not include intervention of interest. [pmid: 15458515].
Aessopos A, Farmakis D, Karagiorga M, et al. Cardiac involvement in thalassemia intermedia: a multicenter study. Blood. 2001;97(11):3411-6. Exclude - Does not include intervention of interest. [pmid: 11369631].
Aessopos A, Stamatelos G, Skoumas V, et al. Pulmonary hypertension and right heart failure in patients with beta-thalassemia intermedia. Chest. 1995;107(1):50-3. Exclude - Does not include intervention of interest. [pmid: 7813310].
Afifi S, Shayan S, Al-Qamari A. Pulmonary hypertension and right ventricular function: interdependence in pathophysiology and management. Int Anesthesiol Clin. 2009;47(1):97-120. Exclude - Not a full publication. [pmid: 19131755].
Agapito AF, Sousa L, Oliveira JA, et al. Eisenmenger syndrome in the adult--experience with new drugs for the treatment of pulmonary hypertension. Rev Port Cardiol. 2005;24(3):421-31. Exclude - No comparisons of interest. [pmid: 15929625].
Aggarwal P, Patial RK, Negi PC, et al. Oral tadalafil in pulmonary artery hypertension: a prospective study. Indian Heart J. 2007;59(4):329-35. Exclude - No study population of interest. [pmid: 19126938].
Aggarwal SK, Mishra J, Sai V, et al. Aortopulmonary window in adults: diagnosis and treatment of late-presenting patients. Congenit Heart Dis. 2008;3(5):341-6. Exclude - Does not include intervention of interest. [pmid: 18837813].
Aguilar RV, Farber HW. Epoprostenol (prostacyclin) therapy in HIV-associated pulmonary hypertension. Am J Respir Crit Care Med. 2000;162(5):1846-50. Exclude - No comparisons of interest. [pmid: 11069824].
Ahearn GS, Tapson VF, Rebeiz A, et al. Electrocardiography to define clinical status in primary pulmonary hypertension and pulmonary arterial hypertension secondary to collagen vascular disease. Chest. 2002;122(2):524-7. Exclude - No comparisons of interest. [pmid: 12171826].
Ahmadi-Simab K, Hellmich B, Gross WL. Bosentan for severe pulmonary arterial hypertension related to systemic sclerosis with interstitial lung disease. Eur J Clin Invest. Suppl 3. 2006;36:44-8. Exclude - No comparisons of interest. [pmid: 16919010].
Ahmed AE, Ibrahim AS, Elshafie SM. Pulmonary hypertension in patients with treated pulmonary tuberculosis: analysis of 14 consecutive cases. Clin Med Insights Circ Respir Pulm Med. 2011;5:1-5. Exclude - No study population of interest. [pmid: 21339885].
Ahmed AM, El-Shamaa MF. Asymptomatic cardiac involvement in children with Systemic Lupus Erythematosus. J Med Sci (Pakistan). 2006;6(6):944-949. Exclude - no primary or secondary outcomes of interest.
Ahmed S, Siddiqui AK, Sadiq A, et al. Echocardiographic abnormalities in sickle cell disease. Am J Hematol. 2004;76(3):195-8. Exclude - Does not include intervention of interest. [pmid: 15224351].
Airo P, Rossi M, Scarsi M, et al. Disease-modifying effects of long-term cyclic iloprost therapy in systemic sclerosis. A retrospective analysis and comparison with a control group. Clin Exp Rheumatol. 2007;25(5):722-7. Exclude - No comparisons of interest. [pmid: 18078620].
Ajami GH, Borzoee M, Radvar M, et al. Comparison of the effectiveness of oral sildenafil versus oxygen administration as a test for feasibility of operation for patients with secondary pulmonary arterial hypertension. Pediatr Cardiol. 2008;29(3):552-5. Exclude - No comparisons of interest. [pmid: 18058160].
Akagi S, Matsubara H, Miyaji K, et al. Additional effects of bosentan in patients with idiopathic pulmonary arterial hypertension already treated with high-dose epoprostenol. Circ J. 2008;72(7):1142-6. Exclude - No comparisons of interest. [pmid: 18577825].
Akagi S, Matsubara H, Ogawa A, et al. Prevention of catheter-related infections using a closed hub system in patients with pulmonary arterial hypertension. Circ J. 2007;71(4):559-64. Exclude - Does not include intervention of interest. [pmid: 17384460].
Akagi S, Nakamura K, Miyaji K, et al. Marked hemodynamic improvements by high-dose epoprostenol therapy in patients with idiopathic pulmonary arterial hypertension. Circ J. 2010;74(10):2200-5. Exclude - No comparisons of interest. [pmid: 20697180].
Akdogan A Kilic L Dogan I Pulmonary hypertension in systemic lupus erythematosus: Pulmonary thromboembolism is the leading cause Int J Cardiol2012155S29Exclude - Not a full publication
Akdogan A, Okutucu S, Kilic L, et al. Is early diagnosis of pulmonary arterial hypertension possible inflammatory rheumatic diseases?. Int J Cardiol. 2012;155:S29-S30. Exclude - Not a full publication.
Akgul F, Seyfeli E, Melek I, et al. Increased QT dispersion in sickle cell disease: effect of pulmonary hypertension. Acta Haematol. 2007;118(1):1-6. Exclude - Does not include intervention of interest. [pmid: 17374947].
Akgul F, Yalcin F, Babayigit C, et al. Right ventricular and pulmonary function in sickle cell disease patients with pulmonary hypertension. Pediatr Cardiol. 2006;27(4):440-6. Exclude - No comparisons of interest. [pmid: 16835804].
Albert NM, Hague K. Managing patients with primary pulmonary hypertension: prostacyclin therapy. Am J Crit Care. 1997;6(4):274-80. Exclude - Not a full publication. [pmid: 9215424].
Aleem A, Jehangir A, Owais M, et al. Echocardiographic abnormalities in adolescent and adult Saudi patients with sickle cell disease. Saudi Med J. 2007;28(7):1072-5. Exclude - Does not include intervention of interest. [pmid: 17603714].
Alehan D, Yildirim I, Sahin M, et al. Long-term inhaled iloprost use in children with pulmonary arterial hypertension. Cardiol Young. 2011:1-8. Exclude - No comparisons of interest. [pmid: 22067137].
Alehan D, Yildirim I, Sahin M, et al. Long-term inhaled iloprost use in children with pulmonary arterial hypertension. Cardiol Young. 2012;22(4):396-403. Exclude - No comparisons of interest. [pmid: 22067137].
Alkassab F, Steen V. Estimated systolic pulmonary artery pressure versus tricuspid regurgitant jet velocity as screening tools for pulmonary hypertension in systemic sclerosis: The pharos experience. Clin Exp Rheumatol. 2010;28(2):S130. Exclude - not a full publication.
Alkon J, Humpl T, Manlhiot C, et al. Usefulness of the right ventricular systolic to diastolic duration ratio to predict functional capacity and survival in children with pulmonary arterial hypertension. Am J Cardiol. 2010;106(3):430-6. Exclude - Does not include intervention of interest. [pmid: 20643259].
Alkotob ML, Soltani P, Sheatt MA, et al. Reduced exercise capacity and stress-induced pulmonary hypertension in patients with scleroderma. Chest. 2006;130(1):176-81. Exclude - Does not include intervention of interest. [pmid: 16840399].
Allanore Y, Borderie D, Meune C, et al. N-terminal pro-brain natriuretic peptide as a diagnostic marker of early pulmonary artery hypertension in patients with systemic sclerosis and effects of calcium-channel blockers. Arthritis Rheum. 2003;48(12):3503-8. Exclude - Does not include intervention of interest. [pmid: 14674001].
Allanore Y, Borderie D, Meune C, et al. Increased plasma soluble CD40 ligand concentrations in systemic sclerosis and association with pulmonary arterial hypertension and digital ulcers. Ann Rheum Dis. 2005;64(3):481-3. Exclude - Does not include intervention of interest. [pmid: 15708899].
Allanore Y, Wahbi K, Borderie D, et al. N-terminal pro-brain natriuretic peptide in systemic sclerosis: a new cornerstone of cardiovascular assessment?. Ann Rheum Dis. 2009;68(12):1885-9. Exclude - no primary or secondary outcomes of interest. [pmid: 19054819].
Al-Otair H. Inhaled iloprost for pulmonary hypertension: Clinical effects of adding inhaled iloprost to existing sildanafil therapy. Ann Thorac Med. 2011;6(3):164-165. Exclude - Not a full publication.
Alpert MA, Pressly TA, Mukerji V, et al. Acute and long-term effects of nifedipine on pulmonary and systemic hemodynamics in patients with pulmonary hypertension associated with diffuse systemic sclerosis, the CREST syndrome and mixed connective tissue disease. Am J Cardiol. 1991;68(17):1687-91. Exclude – no primary or secondary outcomes of interest. [pmid: 1746473].
Altintas A, Karahan Z, Pasa S, et al. Pulmonary hypertension in patients with essential thrombocythemia and reactive thrombocytosis. Leuk Lymphoma. 2007;48(10):1981-7. Exclude - Does not include intervention of interest. [pmid: 17852711].
Amabile N, Heiss C, Chang V, et al. Increased CD62e(+) endothelial microparticle levels predict poor outcome in pulmonary hypertension patients. J Heart Lung Transplant. 2009;28(10):1081-6. Exclude - Does not include intervention of interest. [pmid: 19782291].
Amabile N, Heiss C, Real WM, et al. Circulating endothelial microparticle levels predict hemodynamic severity of pulmonary hypertension. Am J Respir Crit Care Med. 2008;177(11):1268-75. Exclude - Does not include intervention of interest. [pmid: 18310479].
Amaki M, Nakatani S, Kanzaki H, et al. Usefulness of three-dimensional echocardiography in assessing right ventricular function in patients with primary pulmonary hypertension. Hypertens Res. 2009;32(5):419-22. Exclude - No comparisons of interest. [pmid: 19325565].
Ambroz D, Jansa P, Maresova J, et al. Infectious complications of long-term intravenous epoprostenol therapy in patients with pulmonary arterial hypertension. Cor Vasa. 2009;51(7–8):488-490. Exclude - Not available in English.
Ambrusko SJ, Gunawardena S, Sakara A, et al. Elevation of tricuspid regurgitant jet velocity, a marker for pulmonary hypertension in children with sickle cell disease. Pediatr Blood Cancer. 2006;47(7):907-13. Exclude - Does not include intervention of interest. [pmid: 16496290].
Ameling A, Joosten KF, Berger RM. The semi-elective use of the pulmonary artery flotation catheter in children with progressive pulmonary hypertension or left ventricular dysfunction. Pediatr Crit Care Med. 2001;2(3):211-6. Exclude - Does not include intervention of interest. [pmid: 12793943].
Amoozgar H, Farhani N, Karimi M. Early echocardiographic findings in beta-thalassemia intermedia patients using standard and tissue Doppler methods. Pediatr Cardiol. 2011;32(2):154-9. Exclude - Does not include intervention of interest. [pmid: 21082174].
Andrade A, Vargas-Barron J, Rijlaarsdam M, et al. Utility of transesophageal echocardiography in the examination of adult patients with patent ductus arteriosus. Am Heart J. 1995;130(3 Pt 1):543-6. Exclude - Does not include intervention of interest. [pmid: 7661073].
Andreassen AK, Geiran O, Madsen S, et al. Treatment with prostacyclin or calcium channel blockers in pulmonary arterial hypertension. Tidsskr Nor Laegeforen. 2003;123(23):3393-3396. Exclude - Not available in English. [pmid: 14713978].
Angalakuditi M, Edgell E, Beardsworth A, et al. Treatment patterns and resource utilization and costs among patients with pulmonary arterial hypertension in the United States. J Med Econ. 2010;13(3):393-402. Exclude - no primary or secondary outcomes of interest. [pmid: 20608882].
Sildenafil shows some promise for the treatment of pulmonary hypertension. Pharm J. 2001;267(7158):112. Exclude - not a full publication.
New developments in the treatment of scleroderma. Drugs Ther Perspect. 2002;18(2):19-21. Exclude - Not a full publication.
Calcium-channel-blocker response in idiopathic pulmonary arterial hypertension. Nat Clin Pract Cardiovasc Med. 2005;2(8):381. Exclude - Not a full publication.
New agents may permit tailored therapy in PAH. Cardiol Rev. 2005;22(12):6-7. Exclude - Not a full publication.
Treprostinil. Pulmonary artery hypertension: Just another (disappointing) prostacycline analogue. Prescrire Int. 2006;15(85):177-179. Exclude - Not a full publication. [pmid: 17128524].
Bosentan: Also too risky in mildly symptomatic pulmonary arterial hypertension. Prescrire Int. 2009;18(100):55. Exclude - Not a full publication. [pmid: 19585716].
Tadalafil (Adcirca) for pulmonary arterial hypertension. Med Lett Drugs Ther. 2009;51(1324):87-8. Exclude - Not a full publication. [pmid: 19890245].
Ansari S, Usman M, Dalal B, et al. Echocardiographic evaluation of patients with sickle cell disease. Chest. 2011;140(4). Exclude - Not a full publication.
Antoniu SA. Bosentan for treatment of pulmonary arterial hypertension (I). Therapy. 2005;2(6):843-847. Exclude - Not a full publication.
Antoniu SA. Non-prostanoid prostacyclin agonists for the treatment of pulmonary arterial hypertension. Expert Opin Investig Drugs. 2006;15(3):327-30. Exclude - No study population of interest. [pmid: 16503768].
Antoniu SA. Sildenafil citrate for the treatment of pulmonary arterial hypertension. Expert Opin Pharmacother. 2006;7(6):825-8. Exclude - Not a full publication. [pmid: 16556096].
Apfel HD, Shen Z, Gopal AS, et al. Quantitative three dimensional echocardiography in patients with pulmonary hypertension and compressed left ventricles: comparison with cross sectional echocardiography and magnetic resonance imaging. Heart. 1996;76(4):350-4. Exclude - Does not include intervention of interest. [pmid: 8983683].
Apitz C, Reyes JT, Holtby H, et al. Pharmacokinetic and hemodynamic responses to oral sildenafil during invasive testing in children with pulmonary hypertension. J Am Coll Cardiol. 2010;55(14):1456-62. Exclude - No comparisons of interest. [pmid: 20359596].
Apitz C, Zimmermann R, Kreuder J, et al. Assessment of pulmonary endothelial function during invasive testing in children and adolescents with idiopathic pulmonary arterial hypertension. J Am Coll Cardiol. 2012;60(2):157-164. Exclude - Does not include intervention of interest. [pmid: 22766343].
Apostolopoulou SC, Kantzis M, Tsoutsinos A, et al. 15 year experience in pulmonary hypertension due to congenital heart disease before and after targeted therapies: the durability of the right ventricle in this disease. Eur Heart J. 2011;32:174. Exclude - Not a full publication.
Apostolopoulou SC, Kourgiannidis G, Manginas A, et al. Differential vasoactive response to endothelin receptor antagonists and prostacyclin in patients with severe pulmonary hypertension. Clin Sci (Lond). Suppl 48. 2002;103:298S-301S. Exclude - Does not include intervention of interest. [pmid: 12193108].
Apostolopoulou SC, Manginas A, Cokkinos DV, et al. Effect of the oral endothelin antagonist bosentan on the clinical, exercise, and haemodynamic status of patients with pulmonary arterial hypertension related to congenital heart disease. Heart. 2005;91(11):1447-52. Exclude - no comparisons of interest. [pmid: 15761050].
Apostolopoulou SC, Manginas A, Cokkinos DV, et al. Long-term oral bosentan treatment in patients with pulmonary arterial hypertension related to congenital heart disease: a 2-year study. Heart. 2007;93(3):350-4. Exclude - no comparisons of interest. [pmid: 16980516].
Archer SL, Michelakis ED. Phosphodiesterase type 5 inhibitors for pulmonary arterial hypertension. N Engl J Med. 2009;361(19):1864-71. Exclude - Not a full publication. [pmid: 19890129].
Archer SL, Raizner AE. Management of pulmonary hypertension. ACC Cardiosource Rev J. 2007;16(6):35-37. Exclude - Not a full publication.
Argiento P, Chesler N, Mule M, et al. Exercise stress echocardiography for the study of the pulmonary circulation. Eur Respir J. 2010;35(6):1273-8. Exclude - No study population of interest. [pmid: 19926746].
Arkles JS, Opotowsky AR, Ojeda J, et al. Shape of the right ventricular Doppler envelope predicts hemodynamics and right heart function in pulmonary hypertension. Am J Respir Crit Care Med. 2011;183(2):268-76. Exclude - No comparisons of interest. [pmid: 20709819].
Armigliato M, Paolini R, Aggio S, et al. Hyperthyroidism as a cause of pulmonary arterial hypertension: a prospective study. Angiology. 2006;57(5):600-6. Exclude - No comparisons of interest. [pmid: 17067983].
Armstrong DW, Tsimiklis G, Matangi MF. Factors influencing the echocardiographic estimate of right ventricular systolic pressure in normal patients and clinically relevant ranges according to age. Can J Cardiol. 2010;26(2):x35-9. Exclude - No comparisons of interest. [pmid: 20151056].
Arshad MS, Shaikh S. The pattern of ventricular septal defects and the severity of associated pulmonary hypertension in our set-up. Med Forum Monthly. 2011;22(8):55-58. Exclude - unable to obtain full-text.
Arya B, Kerstein D, Leu CS, et al. Echocardiographic assessment of right atrial pressurein a pediatric and young adult population. J Am Soc Echocardiogr. 2012;25(6):B35. Exclude - Not a full publication.
Aschner JL. New therapies for pulmonary hypertension in neonates and children. Pediatr Pulmonol Suppl. 2004;26:132-5. Exclude - Not a full publication. [pmid: 15029628].
Ashfaq M, Chinnakotla S, Rogers L, et al. The impact of treatment of portopulmonary hypertension on survival following liver transplantation. Am J Transplant. 2007;7(5):1258-64. Exclude - No comparisons of interest. [pmid: 17286619].
Asosingh K, Aldred MA, Vasanji A, et al. Circulating angiogenic precursors in idiopathic pulmonary arterial hypertension. Am J Pathol. 2008;172(3):615-27. Exclude - No comparisons of interest. [pmid: 18258847].
Ataga KI, Moore CG, Hillery CA, et al. Coagulation activation and inflammation in sickle cell disease-associated pulmonary hypertension. Haematologica. 2008;93(1):20-6. Exclude - No comparisons of interest. [pmid: 18166781].
Ataga KI, Moore CG, Jones S, et al. Pulmonary hypertension in patients with sickle cell disease: a longitudinal study. Br J Haematol. 2006;134(1):109-15. Exclude - No comparisons of interest. [pmid: 16803576].
Atichartakarn V, Likittanasombat K, Chuncharunee S, et al. Pulmonary arterial hypertension in previously splenectomized patients with beta-thalassemic disorders. Int J Hematol. 2003;78(2):139-45. Exclude - No comparisons of interest. [pmid: 12953808].
Atiq M, Tasneem H, Aziz K. Estimation of pulmonary vascular resistance with Doppler diastolic gradients. Asian Cardiovasc Thorac Ann. 2008;16(3):221-5. Exclude - No comparisons of interest. [pmid: 18515672].
Attaran RR, Ramaraj R, Sorrell VL, et al. Poor correlation of estimated pulmonary artery systolic pressure between echocardiography and right heart catheterization in patients awaiting cardiac transplantation: results from the clinical arena. Transplant Proc. 2009;41(9):3827-30. Exclude - No study population of interest. [pmid: 19917395].
Augoustides JG, Ochroch EA. Inhaled selective pulmonary vasodilators. Int Anesthesiol Clin. 2005;43(2):101-14. Exclude - Not a full publication. [pmid: 15795566].
Auletta M, Oliviero U, Iasiuolo L, et al. Pulmonary hypertension associated with liver cirrhosis: an echocardiographic study. Angiology. 2000;51(12):1013-20. Exclude - No comparisons of interest. [pmid: 11132993].
Avellana P, Segovia J, Sufrate E, et al. Long-term (5 years) effects of bosentan in patients with pulmonary arterial hypertension. Rev Esp Cardiol. 2011;64(8):667-73. Exclude - No comparisons of interest. [pmid: 21719181].
Avouac J, Airo P, Meune C, et al. Point prevalence of pulmonary hypertensions in systemic sclerosis: Results from two large cohorts (of European caucasian patients) and meta-analysis. Clin Exp Rheumatol. 2010;28(2):S129. Exclude - Not a full publication.
Avouac J, Airo P, Meune C, et al. Prevalence of pulmonary hypertension in systemic sclerosis in European Caucasians and metaanalysis of 5 studies. J Rheumatol. 2010;37(11):2290-8. Exclude - Does not include intervention of interest. [pmid: 20810505].
Awadallah S, Halaweish I, Kutayli F. Tele-echocardiography in neonates: utility and benefits in South Dakota primary care hospitals. S D Med. 2006;59(3):97-100. Exclude - No comparisons of interest. [pmid: 16566300].
Azzouni F, Abu samra K. Are phosphodiesterase type 5 inhibitors associated with vision-threatening adverse events? a critical analysis and review of the literature. J Sex Med. 2011;8(10):2894-2903. Exclude - Not a full publication. [pmid: 21771280].
Bacal F, de Freitas AF Jr, Moreira LF, et al. Validation of a cutoff value on echo Doppler analysis to replace right heart catheterization during pulmonary hypertension evaluation in heart transplant candidates. Transplant Proc. 2010;42(2):535-8. Exclude - No comparisons of interest. [pmid: 20304186].
Badesch D, Hwang LJ, Teal S, et al. Posthoc subgroup analysis: Sildenafil (SIL) added to long-term epoprostenol therapy in patients with idiopathic and connective tissue disease (CTD)-associated pulmonary arterial hypertension (PAH). Eur Heart J. 2011;32:173. Exclude - Not a full publication.
Badesch DB, McGoon MD, Barst RJ, et al. Longterm survival among patients with scleroderma-associated pulmonary arterial hypertension treated with intravenous epoprostenol. J Rheumatol. 2009;36(10):2244-9. Exclude - no comparisons of interest. [pmid: 19723905].
Badesch DB, Peschel T, Pizzuti D, et al. Post-marketing hepatic safety profile of ambrisentan in patients with pulmonary arterial hypertension-4 year update. J Heart Lung Transplant. 2012;31(4):S60. Exclude - Not a full publication.
Bagga H, Chia KS, Freeman D, et al. The initial 18 months of the first multi-disciplinary regional Pulmonary Arterial Hypertension Clinic in Australia. Aust J Rural Health. 2011;19(2):89-94. Exclude - No comparisons of interest. [pmid: 21438951].
Bakouboula B, Morel O, Faure A, et al. Procoagulant membrane microparticles correlate with the severity of pulmonary arterial hypertension. Am J Respir Crit Care Med. 2008;177(5):536-43. Exclude - No comparisons of interest. [pmid: 18006886].
Baldovinos A, Kalangos A, Sierra J, et al. Is partially reversible pulmonary hypertension a contraindication for heart transplantation?. Transplant Proc. 2000;32(2):468-9. Exclude - No comparisons of interest. [pmid: 10715482].
Bando K, Vijayaraghavan P, Turrentine MW, et al. Dynamic changes of endothelin-1, nitric oxide, and cyclic GMP in patients with congenital heart disease. Circulation. 1997;96(9 Suppl):II-346-51. Exclude - Does not include intervention of interest. [pmid: 9386122].
Baptista MJ, Correia-Pinto J, Rocha G, et al. Brain-type natriuretic peptide in the diagnosis and management of persistent pulmonary hypertension of the newborn. Pediatrics. 2005;115(4):1111. author reply 1112. Exclude - Not a full publication. [pmid: 15805406].
Baptista MJ, Rocha G, Clemente F, et al. N-terminal-pro-B type natriuretic peptide as a useful tool to evaluate pulmonary hypertension and cardiac function in CDH infants. Neonatology. 2008;94(1):22-30. Exclude - No study population of interest. [pmid: 18160811].
Baquero H, Soliz A, Neira F, et al. Oral sildenafil in infants with persistent pulmonary hypertension of the newborn: a pilot randomized blinded study. Pediatrics. 2006;117(4):1077-83. Exclude - no primary or secondary outcomes of interest. [pmid: 16585301].
Barbosa MM, Lamounier JA, Oliveira EC, et al. Pulmonary hypertension in schistosomiasis mansoni. Trans R Soc Trop Med Hyg. 1996;90(6):663-5. Exclude - no primary or secondary outcomes of interest. [pmid: 9015509].
Barreto AC, Franchi SM, Castro CR, et al. One-year follow-up of the effects of sildenafil on pulmonary arterial hypertension and veno-occlusive disease. Braz J Med Biol Res. 2005;38(2):185-95. Exclude - No comparisons of interest. [pmid: 15785829].
Barreto AC, Maeda NY, Soares RP, et al. Rosuvastatin and vascular dysfunction markers in pulmonary arterial hypertension: a placebo-controlled study. Braz J Med Biol Res. 2008;41(8):657-63. Exclude - No comparisons of interest. [pmid: 18797697].
Barst R, Russell S, Oudiz R, et al. Effects of oral sildenafil treatment on exercise capacity in pediatric pulmonary arterial hypertension (PAH). Chest. 2011;140(4). Exclude - Not a full publication.
Barst RJ. Long-term prostacyclin reduces pulmonary vascular resistance in severe primary pulmonary hypertension. Clin Exp Rheumatol. 1998;16(3):253-4. Exclude - Not a full publication. [pmid: 9631745].
Barst RJ, Galie N, Naeije R, et al. Long-term outcome in pulmonary arterial hypertension patients treated with subcutaneous treprostinil. Eur Respir J. 2006;28(6):1195-203. Exclude - no comparisons of interest. [pmid: 16899485].
Barst RJ, Ivy D, Dingemanse J, et al. Pharmacokinetics, safety, and efficacy of bosentan in pediatric patients with pulmonary arterial hypertension. Clin Pharmacol Ther. 2003;73(4):372-82. Exclude - No comparisons of interest. [pmid: 12709727].
Barst RJ, Kato GJ, Sachdev V, et al. Predictors of six-minute walk distance in adults with sickle cell anemia in the walk-PHaSST study. Blood. 2010;116(21). Exclude - Not a full publication.
Barst RJ, Maislin G, Fishman AP. Vasodilator therapy for primary pulmonary hypertension in children. Circulation. 1999;99(9):1197-208. Exclude - no comparisons of interest. [pmid: 10069788].
Bartosik I, Eskilsson J, Ekman R, et al. Correlation between plasma concentrations of calcitonin gene related peptide and pulmonary pressure in patients with systemic sclerosis. Ann Rheum Dis. 2002;61(3):261-3. Exclude - No comparisons of interest. [pmid: 11830435].
Baskar Karthekeyan R, Saldanha R, Sahadevan MR, et al. Scimitar syndrome: experience with 6 patients. Asian Cardiovasc Thorac Ann. 2009;17(3):266-71. Exclude - Not a full publication. [pmid: 19643850].
Bassyouni IH, Gheita TA, Talaat RM. Clinical significance of serum levels of sCD36 in patients with systemic sclerosis: preliminary data. Rheumatology (Oxford). 2011;50(11):2108-12. Exclude - No comparisons of interest. [pmid: 21890620].
Batal O, Buchanan K, Elliott A, et al. Does obesity affect brain natriuretic peptide levels in patients with pulmonary arterial hypertension?. J Am Coll Cardiol. 2012;59(13):E1591. Exclude - Not a full publication.
Battle RW, Davitt MA, Cooper SM, et al. Prevalence of pulmonary hypertension in limited and diffuse scleroderma. Chest. 1996;110(6):1515-9. Exclude - No comparisons of interest. [pmid: 8989070].
Baughman RP, Judson MA, Lower EE, et al. Inhaled iloprost for sarcoidosis associated pulmonary hypertension. Sarcoidosis Vasc Diffuse Lung Dis. 2009;26(2):110-20. Exclude - No comparisons of interest. [pmid: 20560291].
Baysal A, Yildirim A, Sasmazel A, et al. The prognostic value of plasma B-type natriuretic peptide in children with pulmonary hypertension undergoing congenital heart disease surgery. Appl Cardiopulm Pathophysiol. 2012;16:200-201. Exclude - Not a full publication.
Bech-Hanssen O, Lindgren F, Selimovic N, et al. Echocardiography can identify patients with increased pulmonary vascular resistance by assessing pressure reflection in the pulmonary circulation. Circ Cardiovasc Imaging. 2010;3(4):424-32. Exclude - no primary or secondary outcomes of interest. [pmid: 20448141].
Bech-Hanssen O, Selimovic N, Rundqvist B, et al. Doppler echocardiography can provide a comprehensive assessment of right ventricular afterload. J Am Soc Echocardiogr. 2009;22(12):1360-7. Exclude - no primary or secondary outcomes of interest. [pmid: 19880275].
Becvar R, Jansa P, Stork J, et al. Epidemiological study of pulmonary arterial hypertension related to systemic sclerosis in the Czech Republic. Clin Exp Rheumatol. 2010;28(2):S129. Exclude - Not a full publication.
Beghetti M, Haworth SG, Bonnet D, et al. Pharmacokinetic and clinical profile of a novel formulation of bosentan in children with pulmonary arterial hypertension: the FUTURE-1 study. Br J Clin Pharmacol. 2009;68(6):948-55. Exclude - No comparisons of interest. [pmid: 20002090].
Beghetti M, Hoeper MM, Kiely DG, et al. Safety experience with bosentan in 146 children 2–11 years old with pulmonary arterial hypertension: results from the European Postmarketing Surveillance program. Pediatr Res. 2008;64(2):200-4. Exclude - No comparisons of interest. [pmid: 18414142].
Behzadnia N, Najafizadeh K, Sharif-Kashani B, et al. Noninvasive assessment of acute cardiopulmonary effects of an oral single dose of sildenafil in patients with idiopathic pulmonary hypertension. Heart Vessels. 2010;25(4):313-8. Exclude - No comparisons of interest. [pmid: 20676840].
Belden H. New PAH drug improves exercise capacity. Drug Topics. 2007;151(14). Exclude - Not a full publication.
Belenkov Yu N, Chazova IE, Samko AN, et al. Use of a calcium antagonist isradipine in patients with primary pulmonary hypertension. Kardiologiya. 1995;35(7):9-13. Exclude - Not available in English.
Benatar A, Clarke J, Silverman M. Pulmonary hypertension in infants with chronic lung disease: non-invasive evaluation and short term effect of oxygen treatment. Arch Dis Child Fetal Neonatal Ed. 1995;72(1):F14-9. Exclude - No comparisons of interest. [pmid: 7743277].
Bendayan D, Fink G, Aravot D, et al. Continuous intravenous epoprostenol in pulmonary hypertension: the Israel experience. Isr Med Assoc J. 2002;4(4):255-8. Exclude - No comparisons of interest. [pmid: 12001697].
Ben-Dor I, Kramer MR, Raccah A, et al. Echocardiography versus right-sided heart catheterization among lung transplantation candidates. Ann Thorac Surg. 2006;81(3):1056-60. Exclude - No study population of interest. [pmid: 16488722].
Benjaminov FS, Prentice M, Sniderman KW, et al. Portopulmonary hypertension in decompensated cirrhosis with refractory ascites. Gut. 2003;52(9):1355-62. Exclude - No comparisons of interest. [pmid: 12912870].
Benza R, Gotzkowsky K, Jenkins A, et al. Effect of earlier initiation of inhaled treprostinil (ITRE) on long term outcomes in patients with pulmonary arterial hypertension (PAH). Chest. 2011;140(4). Exclude - Not a full publication.
Benza RL, Gomberg-Maitland M, Miller DP, et al. The REVEAL Registry risk score calculator in patients newly diagnosed with pulmonary arterial hypertension. Chest. 2012;141(2):354-62. Exclude - no primary or secondary outcomes of interest. [pmid: 21680644].
Benza RL, Gomberg-Maitland M, Naeije R, et al. Prognostic factors associated with increased survival in patients with pulmonary arterial hypertension treated with subcutaneous treprostinil in randomized, placebo-controlled trials. J Heart Lung Transplant. 2011;30(9):982-9. Exclude - Does not include intervention of interest. [pmid: 21531577].
Benza RL, Rayburn BK, Tallaj JA, et al. Efficacy of bosentan in a small cohort of adult patients with pulmonary arterial hypertension related to congenital heart disease. Chest. 2006;129(4):1009-15. Exclude - No comparisons of interest. [pmid: 16608951].
Benza RL, Rayburn BK, Tallaj JA, et al. Treprostinil-based therapy in the treatment of moderate-to-severe pulmonary arterial hypertension: long-term efficacy and combination with bosentan. Chest. 2008;134(1):139-45. Exclude - no comparisons of interest. [pmid: 18403673].
Benza RL, Seeger W, McLaughlin VV, et al. Long-term effects of inhaled treprostinil in patients with pulmonary arterial hypertension: The TReprostinil sodium Inhalation Used in the Management of Pulmonary arterial Hypertension (TRIUMPH) study open-label extension. J Heart Lung Transplant. 2011;30(12):1327-1333. Exclude - no comparisons of interest. [pmid: 22055098].
Beretta L, Caronni M, Origgi L, et al. Hormone replacement therapy may prevent the development of isolated pulmonary hypertension in patients with systemic sclerosis and limited cutaneous involvement. Scand J Rheumatol. 2006;35(6):468-71. Exclude - Does not include intervention of interest. [pmid: 17343256].
Berger RM, Beghetti M, Galie N, et al. Atrial septal defects versus ventricular septal defects in BREATHE-5, a placebo-controlled study of pulmonary arterial hypertension related to Eisenmenger’s syndrome: a subgroup analysis. Int J Cardiol. 2010;144(3):373-8. Exclude - No study population of interest. [pmid: 19464064].
Bergot E, Sitbon O, Cottin V, et al. Current epoprostenol use in patients with severe pulmonary hypertension (PH): Data from the French PH registry. Eur Heart J. 2011;32:172-173. Exclude - Not a full publication.
Bernal V, Pascual I, Esquivias P, et al. N-terminal brain natriuretic peptide as a diagnostic test in cirrhotic patients with pulmonary arterial hypertension. Transplant Proc. 2009;41(3):987-8. Exclude - no primary or secondary outcomes of interest. [pmid: 19376405].
Beyer J, Kolditz M, Ewert R, et al. L-arginine plasma levels and severity of idiopathic pulmonary arterial hypertension. Vasa. 2008;37(1):61-7. Exclude - Does not include intervention of interest. [pmid: 18512543].
Beyer S, Speich R, Fischler M, et al. Long-term experience with oral or inhaled vasodilator combination therapy in patients with pulmonary hypertension. Swiss Med Wkly. 2006;136(7–8):114-8. Exclude - Does not include intervention of interest. [pmid: 16633955].
Bharani A, Mathew V, Sahu A, et al. The efficacy and tolerability of sildenafil in patients with moderate-to-severe pulmonary hypertension. Indian Heart J. 2003;55(1):55-9. Exclude - No comparisons of interest. [pmid: 12760589].
Bhatia S, Frantz RP, Severson CJ, et al. Immediate and long-term hemodynamic and clinical effects of sildenafil in patients with pulmonary arterial hypertension receiving vasodilator therapy. Mayo Clin Proc. 2003;78(10):1207-13. Exclude - No comparisons of interest. [pmid: 14531479].
Billy-Brissac R, Blanchet-Deverly A, Etienne-Julan M, et al. Pulmonary hypertension in an adult sickle cell population in Guadeloupe. Int J Cardiol. 2009;135(1):122-3. Exclude - No comparisons of interest. [pmid: 18466988].
Blagnjevic J, Pallini F, Peruzzi F, et al. Detection of nulllatentnull pulmonary arterial hypertension (PAH) in systemic sclerosis (SSC): The usefulness of non invasive echocardiography. Clin Exp Rheumatol. 2010;28(2):S131. Exclude - Not a full publication. [pmid: 21176433].
Blagnjevic J, Pallini F, Peruzzi F, et al. Bosentan for exercise induced pulmonary arterial hypertension in systemic sclerosis: Results from an open study. Clin Exp Rheumatol. 2010;28(2):S131. Exclude - Not a full publication. [pmid: 21176433].
Blalock SE, Matulevicius S, Mitchell LC, et al. Long-term outcomes with ambrisentan monotherapy in pulmonary arterial hypertension. J Card Fail. 2010;16(2):121-7. Exclude - no comparisons of interest. [pmid: 20142023].
Blumberg FC, Riegger GA, Pfeifer M. Hemodynamic effects of aerosolized iloprost in pulmonary hypertension at rest and during exercise. Chest. 2002;121(5):1566-71. Exclude - No comparisons of interest. [pmid: 12006445].
Bombardini T, Sicari R, Bianchini E, et al. Abnormal shortened diastolic time length at increasing heart rates in patients with abnormal exercise-induced increase in pulmonary artery pressure. Cardiovasc Ultrasound. 2011;9:36. Exclude - No study population of interest. [pmid: 22104611].
Bonino C, Cavagna L, Caporali R, et al. Head to head comparison of brain natriuretic peptide and NT-proBNP in the screening of pulmonary arterial hypertension in systemic sclerosis patients. Clin Exp Rheumatol. 2010;28(2):S129. Exclude - Not a full publication.
Bonnet D, Jas X, Rottat L, et al. Characteristics of PAH associated with pretricuspid shunts in the registry of the French PAH network. Cardiol Young. 2012;22:S29-S30. Exclude - Not a full publication.
Bonnet D, Levy M, Mauge L, et al. Circulating endothelial cell levels decrease after vasodilator therapy and are a biomarker of deterioration in pediatric pulmonary hypertension. Cardiol Young. 2012;22:S40. Exclude - Not a full publication.
Bossone E, Duong-Wagner TH, Paciocco G, et al. Echocardiographic features of primary pulmonary hypertension. J Am Soc Echocardiogr. 1999;12(8):655-62. Exclude - No comparisons of interest. [pmid: 10441222].
Bouchard JL, Aurigemma GP, Hill JC, et al. Usefulness of the pulmonary arterial systolic pressure to predict pulmonary arterial wedge pressure in patients with normal left ventricular systolic function. Am J Cardiol. 2008;101(11):1673-6. Exclude - No study population of interest. [pmid: 18489950].
Bozbas SS, Bozbas H, Atar A, et al. Comparative effects of losartan and nifedipine therapy on exercise capacity, Doppler echocardiographic parameters and endothelin levels in patients with secondary pulmonary hypertension. Anadolu Kardiyol Derg. 2010;10(1):43-9. Exclude - No study population of interest. [pmid: 20150004].
Bozbas SS, Yilmaz EB, Dogrul I, et al. Preoperative pulmonary evaluation of liver transplant candidates: Results from 341 adult patients. Ann Transplant. 2011;16(3):88-96. Exclude - no primary or secondary outcomes of interest. [pmid: 21959515].
Brady CJ. Improving access to pulmonary care for children with sickle cell disease. Am J Hematol. 2011;86(10):E32-E33. Exclude - Not a full publication.
Bratel T, Lagerstrand L, Brodin LA, et al. Ventilation/perfusion ratios in pulmonary arterial hypertension: effects of IV and inhaled prostacyclin derivatives. Chest. 2005;128(6 Suppl):615S-616S. Exclude - Not a full publication. [pmid: 16373868].
Bratel T, Lagerstrand L, Brodin LA, et al. Ventilation-perfusion relationships in pulmonary arterial hypertension: effect of intravenous and inhaled prostacyclin treatment. Respir Physiol Neurobiol. 2007;158(1):59-69. Exclude - Does not include intervention of interest. [pmid: 17452130].
Bream-Rouwenhorst HR, Hobbs RA. Pulmonary hypertension: An update. US Pharm. 2008;33(8). Exclude - Not a full publication.
Brechot N, Gambotti L, Lafitte S, et al. Usefulness of right ventricular isovolumic relaxation time in predicting systolic pulmonary artery pressure. Eur J Echocardiogr. 2008;9(4):547-54. Exclude - No comparisons of interest. [pmid: 18490309].
Brenot F, Herve P, Petitpretz P, et al. Primary pulmonary hypertension and fenfluramine use. Br Heart J. 1993;70(6):537-41. Exclude – does not include intervention of interest. [pmid: 8280518].
Bright J, Shumoogam J, Tear S. Deal highlights. IDrugs. 2007;10(10):732-735. Exclude - Not a full publication.
Brili SSV, Stamatopoulos H, Misailidou M, et al. Longitudinal strain curves of the RV free wall differ in morphology in patients with pulmonary hypertension compared with controls. Eur Heart J. 2011;32:117. Exclude - Not a full publication.
Brittain JE, Hulkower B, Jones SK, et al. Placenta growth factor in sickle cell disease: association with hemolysis and inflammation. Blood. 2010;115(10):2014-20. Exclude - No comparisons of interest. [pmid: 20040765].
Brown SB, Raina A, Katz D, et al. Longitudinal shortening accounts for the majority of right ventricular contraction and improves after pulmonary vasodilator therapy in normal subjects and patients with pulmonary arterial hypertension. Chest. 2011;140(1):27-33. Exclude - No comparisons of interest. [pmid: 21106653].
Brun H, Holmstrom H, Thaulow E, et al. Patients with pulmonary hypertension related to congenital systemic-to-pulmonary shunts are characterized by inflammation involving endothelial cell activation and platelet-mediated inflammation. Congenit Heart Dis. 2009;4(3):153-9. Exclude - No comparisons of interest. [pmid: 19489942].
Brun H, Moller T, Fredriksen PM, et al. Mechanisms of exercise-induced pulmonary hypertension in patients with cardiac septal defects. Pediatr Cardiol. 2012;33(5):782-790. Exclude - no primary or secondary outcomes of interest. [pmid: 22383098].
Bull TM, Golpon H, Hebbel RP, et al. Circulating endothelial cells in pulmonary hypertension. Thromb Haemost. 2003;90(4):698-703. Exclude - No comparisons of interest. [pmid: 14515191].
Bushuev VI, Miasnikova GY, Sergueeva AI, et al. Endothelin-1, vascular endothelial growth factor and systolic pulmonary artery pressure in patients with Chuvash polycythemia. Haematologica. 2006;91(6):744-9. Exclude - No comparisons of interest. [pmid: 16769575].
Busteed S, Moots RJ, Thompson RN. Screening for pulmonary arterial hypertension in systemic sclerosis. Rheumatology (Oxford). 2004;43(10):1315-6. author reply 1316. Exclude - Not a full publication. [pmid: 15448224].
Butt AY, Higenbottam T. New therapies for primary pulmonary hypertension. Chest. 1994;105(2 Suppl):21S-25S. Exclude – not a full publication. [pmid: 8110298].
Cacoub P, Dorent R, Nataf P, et al. Endothelin-1 in the lungs of patients with pulmonary hypertension. Cardiovasc Res. 1997;33(1):196-200. Exclude - Does not include intervention of interest. [pmid: 9059544].
Cada DJ, Levien T, Baker DE. Treprostinil sodium injection. Hosp Pharm. 2002;37(11):1196-1204. Exclude - Not a full publication.
Cada DJ, Levien T, Baker DE. Ambrisentan Hosp Pharm. 2007;42(12):1145-1154. Exclude - Not a full publication.
Cadeddu Dessalvi C, Caeddu F, Lilliu M, et al. Usefulness of exercise echocardiography in the evaluation of left ventricular impairment in systemic sclerosis patients. Eur Heart J. 2011;32:601. Exclude - Not a full publication.
Callejas-Rubio JL, Moreno-Escobar E, de la Fuente PM, et al. Prevalence of exercise pulmonary arterial hypertension in scleroderma. J Rheumatol. 2008;35(9):1812-6. Exclude - No comparisons of interest. [pmid: 18634147].
Can MM, Kaymaz C, Tanboga IH, et al. Increased right ventricular glucose metabolism in patients with pulmonary arterial hypertension. Clin Nucl Med. 2011;36(9):743-8. Exclude - No comparisons of interest. [pmid: 21825840].
Can MM, Tanboga IH, Demircan HC, et al. Enhanced hemostatic indices in patients with pulmonary arterial hypertension: an observational study. Thromb Res. 2010;126(4):280-2. Exclude - No comparisons of interest. [pmid: 20673969].
Can MM, Tanboga IH, Tokgoz HC, et al. The prognostic value of FDG PET/CT uptake of bone marrow in patients with idiopathic pulmonary arterial hypertension. Eur Heart J. 2011;32:434. Exclude - Not a full publication.
Cappelleri JC, Hwang LJ, Mardekian J, et al. Measurement properties of peak VO2 in children with pulmonary arterial hypertension. Value Health. 2010;13(7):A367. Exclude - Not a full publication.
Cappelleri JC, Hwang LJ, Mardekian J, et al. Response profiles of sildenafil citrate on exercise capacity, hemodynamic function, and health-related quality of life in children with pulmonary arterial hypertension. Value Health. 2010;13(7):A343. Exclude - Not a full publication.
Caramaschi P, Volpe A, Tinazzi I, et al. Does cyclically iloprost infusion prevent severe isolated pulmonary hypertension in systemic sclerosis? Preliminary results. Rheumatol Int. 2006;27(2):203-5. Exclude - No comparisons of interest. [pmid: 17006704].
Caravita S, Wu SC, Secchi MB, et al. Long-term effects of intermittent Iloprost infusion on pulmonary arterial pressure in connective tissue disease. Eur J Intern Med. 2011;22(5):518-521. Exclude - no primary or secondary outcomes of interest. [pmid: 21925064].
Carroll CL, Backer CL, Mavroudis C, et al. Inhaled prostacyclin following surgical repair of congenital heart disease--a pilot study. J Card Surg. 2005;20(5):436-9. Exclude - No comparisons of interest. [pmid: 16153274].
Cartin-Ceba R, Swanson K, Iyer V, et al. Safety and efficacy of ambrisentan for the treatment of portopulmonary hypertension. Chest. 2011;139(1):109-14. Exclude - No comparisons of interest. [pmid: 20705798].
Carulli MT, Handler C, Coghlan JG, et al. Can CCL2 serum levels be used in risk stratification or to monitor treatment response in systemic sclerosis?. Ann Rheum Dis. 2008;67(1):105-9. Exclude - No comparisons of interest. [pmid: 17604287].
Castelain V, Chemla D, Humbert M, et al. Pulmonary artery pressure-flow relations after prostacyclin in primary pulmonary hypertension. Am J Respir Crit Care Med. 2002;165(3):338-40. Exclude - No comparisons of interest. [pmid: 11818317].
Castillo-Palma MJ, Garcia-Hernandez FJ, Gonzalez-Leon R, et al. Pulmonary hypertension in a series of patients with SSc Prevalence of different variants. Rheumatology (Oxford). 2012;51:ii91-ii92. Exclude - Not a full publication.
Castro PF, Greig D, Verdejo HE, et al. Intrapulmonary shunting associated with sildenafil treatment in a patient with idiopathic pulmonary arterial hypertension. Thorax. 2011;66(12):1097-8. Exclude - Not a full publication. [pmid: 21289023].
Cefle A, Inanc M, Sayarlioglu M, et al. Pulmonary hypertension in systemic lupus erythematosus: relationship with antiphospholipid antibodies and severe disease outcome. Rheumatol Int. 2011;31(2):183-9. Exclude - No comparisons of interest. [pmid: 20012052].
Cella G, Bellotto F, Tona F, et al. Plasma markers of endothelial dysfunction in pulmonary hypertension. Chest. 2001;120(4):1226-30. Exclude - No comparisons of interest. [pmid: 11591565].
Chadha C, Pritzker M, Mariash CN. Effect of epoprostenol on the thyroid gland: enlargement and secretion of thyroid hormone. Endocr Pract. 2009;15(2):116-21. Exclude - No study population of interest. [pmid: 19289321].
Chang B, Wigley FM, White B, et al. Scleroderma patients with combined pulmonary hypertension and interstitial lung disease. J Rheumatol. 2003;30(11):2398-405. Exclude - No comparisons of interest. [pmid: 14677184].
Channick R, Badesch DB, Tapson VF, et al. Effects of the dual endothelin receptor antagonist bosentan in patients with pulmonary hypertension: a placebo-controlled study. J Heart Lung Transplant. 2001;20(2):262-263. Exclude - Not a full publication. [pmid: 11250530].
Channick RN, Olschewski H, Seeger W, et al. Safety and efficacy of inhaled treprostinil as add-on therapy to bosentan in pulmonary arterial hypertension. J Am Coll Cardiol. 2006;48(7):1433-7. Exclude - No comparisons of interest. [pmid: 17010807].
Chapman PJ, Bateman ED, Benatar SR. Prognostic and therapeutic considerations in clinical primary pulmonary hypertension. Respir Med. 1990;84(6):489-94. Exclude – no primary or secondary outcomes of interest. [pmid: 2274688].
Charloux A, Chaouat A, Piquard F, et al. Renal hyporesponsiveness to brain natriuretic peptide: both generation and renal activity of cGMP are decreased in patients with pulmonary hypertension. Peptides. 2006;27(11):2993-9. Exclude - Does not include intervention of interest. [pmid: 16822585].
Chau EM, Fan KY, Chow WH. Effects of chronic sildenafil in patients with Eisenmenger syndrome versus idiopathic pulmonary arterial hypertension. Int J Cardiol. 2007;120(3):301-5. Exclude - No comparisons of interest. [pmid: 17174418].
Chaudhry TA, Younas M, Baig A. Ventricular Septal defect and associated complications. J Pak Med Assoc. 2011;61(10):1001-1004. Exclude - no primary or secondary outcomes of interest. [pmid: 22356036].
Chaudry RA, Cikes M, Karu T, et al. Paediatric sickle cell disease: pulmonary hypertension but normal vascular resistance. Arch Dis Child. 2011;96(2):131-6. Exclude - No comparisons of interest. [pmid: 21030373].
Chen JM, Levin HR, Michler RE, et al. Reevaluating the significance of pulmonary hypertension before cardiac transplantation: determination of optimal thresholds and quantification of the effect of reversibility on perioperative mortality. J Thorac Cardiovasc Surg. 1997;114(4):627-34. Exclude - No comparisons of interest. [pmid: 9338649].
Chen L, Zhong W, Xin Z, et al. Summerization of adverse drug reaction of Vardenafil in treatment of 2062 patients. Chin J Androl. 2009;23(1):35-38. Exclude - not available in English.
Chin KM, Badesch DB, Robbins IM, et al. Veletri(registered trademark) and Flolan(registered trademark) (epoprostenol sodium) in the treatment of pulmonary arterial hypertension. J Heart Lung Transplant. 2012;31(4):S28. Exclude - Not a full publication.
Chin KM, Channick RN, de Lemos JA, et al. Hemodynamics and epoprostenol use are associated with thrombocytopenia in pulmonary arterial hypertension. Chest. 2009;135(1):130-6. Exclude - No comparisons of interest. [pmid: 18719056].
Chin KM, Kingman M, de Lemos JA, et al. Changes in right ventricular structure and function assessed using cardiac magnetic resonance imaging in bosentan-treated patients with pulmonary arterial hypertension. Am J Cardiol. 2008;101(11):1669-72. Exclude - No comparisons of interest. [pmid: 18489949].
Chockalingam A, Gnanavelu G, Venkatesan S, et al. Efficacy and optimal dose of sildenafil in primary pulmonary hypertension. Int J Cardiol. 2005;99(1):91-5. Exclude - No comparisons of interest. [pmid: 15721505].
Chua R, Keogh AM, Byth K, et al. Comparison and validation of three measures of quality of life in patients with pulmonary hypertension. Intern Med J. 2006;36(11):705-10. Exclude - Does not include intervention of interest. [pmid: 17040356].
Chung L, Liu J, Parsons L, et al. Characterization of connective tissue disease-associated pulmonary arterial hypertension from REVEAL: Identifying systemic sclerosis as a unique phenotype. Chest. 2010;138(6):1383-1394. Exclude - no primary or secondary outcomes of interest. [pmid: 20507945].
Chung L, Parsons LS, Hassoun PM, et al. Functional class change in patients with connective tissue disease-associated pulmonary arterial hypertension: Associations with survival and exercise capacity. Arthritis Rheum. 2011;63(10). Exclude - Not a full publication.
Chung SM, Lee CK, Lee EY, et al. Clinical aspects of pulmonary hypertension in patients with systemic lupus erythematosus and in patients with idiopathic pulmonary arterial hypertension. Clin Rheumatol. 2006;25(6):866-72. Exclude - No comparisons of interest. [pmid: 16496078].
Cioffi G, de Simone G, Mureddu G, et al. Right atrial size and function in patients with pulmonary hypertension associated with disorders of respiratory system or hypoxemia. Eur J Echocardiogr. 2007;8(5):322-31. Exclude - No study population of interest. [pmid: 16876482].
Ciurzynski M, Bienias P, Irzyk K, et al. Endothelin and N-terminal pro-B type natriuretic peptide reflect impaired right ventricular function and decreased exercise capacity in patients with systemic sclerosis. Eur Heart J. 2011;32:823. Exclude - Not a full publication.
Ciurzynski M, Bienias P, Lichodziejewska B, et al. Non-invasive diagnostic and functional evaluation of cardiac involvement in patients with systemic sclerosis. Clin Rheumatol. 2008;27(8):991-7. Exclude - No comparisons of interest. [pmid: 18256871].
Ciurzynski M, Bienias P, Pruszczyk P. Should patients with connective tissue disease undergo exercise Doppler echocardiography?. Chest. 2010;138(6):1523-4. author reply 1524. Exclude - Not a full publication. [pmid: 21138893].
Clements PJ, Tan M, McLaughlin VV, et al. The pulmonary arterial hypertension quality enhancement research initiative: comparison of patients with idiopathic PAH to patients with systemic sclerosis-associated PAH. Ann Rheum Dis. 2011. Exclude - No comparisons of interest. [pmid: 21998119].
Clements PJ, Tan M, McLaughlin VV, et al. The pulmonary arterial hypertension quality enhancement research initiative: comparison of patients with idiopathic PAH to patients with systemic sclerosis-associated PAH. Ann Rheum Dis. 2012;71(2):249-52. Exclude - no primary or secondary outcomes of interest. [pmid: 21998119].
Cockrill BA, Kacmarek RM, Fifer MA, et al. Comparison of the effects of nitric oxide, nitroprusside, and nifedipine on hemodynamics and right ventricular contractility in patients with chronic pulmonary hypertension. Chest. 2001;119(1):128-36. Exclude - No comparisons of interest. [pmid: 11157594].
Codullo V, Cuomo G, Fusetti C, et al. Exercise echocardiography in SSc: Predictive role in the development of pulmonary hypertension. Rheumatology (Oxford). 2012;51:ii11-ii12. Exclude - Not a full publication.
Codullo V, Cuomo G, Fusetti C, et al. Features of SSc patients with inappropriate exercise-induced increase in pulmonary artery pressure estimated by echocardiography. Rheumatology (Oxford). 2012;51:ii12. Exclude - Not a full publication.
Cohen AJ, Cool C, Gorg S, et al. Low or absent peptidase expression in plexiform lesions of primary pulmonary hypertension. Chest. 1998;114(1 Suppl):30S-31S. Exclude - Not a full publication. [pmid: 9676613].
Collados MT, Sandoval J, Lopez S, et al. Characterization of von Willebrand factor in primary pulmonary hypertension. Heart Vessels. 1999;14(5):246-52. Exclude - No comparisons of interest. [pmid: 10830921].
Collados MT, Velazquez B, Borbolla JR, et al. Endothelin-1 and functional tissue factor: a possible relationship with severity in primary pulmonary hypertension. Heart Vessels. 2003;18(1):12-7. Exclude - No comparisons of interest. [pmid: 12644876].
Colli AM, Ciarmoli E, Gangi S, et al. Predictors of medium-term treatment of pulmonary hypertension in a population of very and extremely low birthweight (VLBW, ELBW) preterm infants. G Ital Cardiol. 2011;12(10):14S-15S. Exclude - Not a full publication.
Collins N, Bastian B, Quiqueree L, et al. Abnormal pulmonary vascular responses in patients registered with a systemic autoimmunity database: Pulmonary Hypertension Assessment and Screening Evaluation using stress echocardiography (PHASE-I). Eur J Echocardiogr. 2006;7(6):439-46. Exclude - No comparisons of interest. [pmid: 16431161].
Colombatti R, Maschietto N, Varotto E, et al. Pulmonary hypertension in sickle cell disease children under 10 years of age. Br J Haematol. 2010;150(5):601-9. Exclude - No comparisons of interest. [pmid: 20553267].
Condino AA, Ivy DD, O’Connor JA, et al. Portopulmonary hypertension in pediatric patients. J Pediatr. 2005;147(1):20-6. Exclude - No comparisons of interest. [pmid: 16027687].
Condliffe R, Pickworth J, Hopkinson K, et al. Serum osteoprotegerin predicts mortality in a prospective study on incident cases of pulmonary arterial hypertension. Thorax. 2011;66:A34. Exclude - Not a full publication.
Condo M, Evans N, Bellu R, et al. Echocardiographic assessment of ductal significance: Retrospective comparison of two methods. Arch Dis Child Fetal Neonatal Ed. 2012;97(1):F35-F38. Exclude - No comparisons of interest. [pmid: 21546401].
Conficoni E, Leci E, Palazzini M, et al. Effects of s.c. treprostinil on top of double oral combination therapy in patients with pulmonary arterial hypertensione (PAH) and inoperable chronic thromboembolic pulmonary hypertension (CTEPH). Eur Heart J. 2011;32:173. Exclude - Not a full publication.
Conte JV, Gaine SP, Orens JB, et al. The influence of continuous intravenous prostacyclin therapy for primary pulmonary hypertension on the timing and outcome of transplantation. J Heart Lung Transplant. 1998;17(7):679-85. Exclude - No comparisons of interest. [pmid: 9703232].
Coral-Alvarado P, Quintana G, Garces MF, et al. Potential biomarkers for detecting pulmonary arterial hypertension in patients with systemic sclerosis. Rheumatol Int. 2009;29(9):1017-24. Exclude - No comparisons of interest. [pmid: 19116719].
Coral-Alvarado PX, Garces MF, Caminos JE, et al. Serum endoglin levels in patients suffering from systemic sclerosis and elevated systolic pulmonary arterial pressure. Intl J Rheumatol. 2010;2010. Exclude - no primary or secondary outcomes of interest.
Cornwell WK, McLaughlin VV, Krishnan SM, et al. Does the outcome justify an oral-first treatment strategy for management of pulmonary arterial hypertension?. Chest. 2011;140(3):697-705. Exclude - No comparisons of interest. [pmid: 21622545].
Costard-Jackle A, Fowler MB. Influence of preoperative pulmonary artery pressure on mortality after heart transplantation: testing of potential reversibility of pulmonary hypertension with nitroprusside is useful in defining a high risk group. J Am Coll Cardiol. 1992;19(1):48-54. Exclude – does not include intervention of interest. [pmid: 1729345].
Cotrim C, Simoes O, Loureiro MJ, et al. Stress echocardiography in the evaluation of exercise physiology in patients with severe arterial pulmonary hypertension. New methodology. Rev Port Cardiol. 2005;24(12):1451-60. Exclude - No comparisons of interest. [pmid: 16566404].
Cotton CL, Gandhi S, Vaitkus PT, et al. Role of echocardiography in detecting portopulmonary hypertension in liver transplant candidates. Liver Transpl. 2002;8(11):1051-4. Exclude - No comparisons of interest. [pmid: 12424719].
Cozzi F, Montisci R, Marotta H, et al. Bosentan therapy of pulmonary arterial hypertension in connective tissue diseases. Eur J Clin Invest. Suppl 3. 2006;36:49-53. Exclude - No comparisons of interest. [pmid: 16919011].
Cracowski JL, Cracowski C, Bessard G, et al. Increased lipid peroxidation in patients with pulmonary hypertension. Am J Respir Crit Care Med. 2001;164(6):1038-42. Exclude - No comparisons of interest. [pmid: 11587993].
Croxtall JD, Lyseng-Williamson KA. Tadalafil: in pulmonary arterial hypertension. Drugs. 2010;70(4):479-88. Exclude - Not a full publication. [pmid: 20205489].
Dadfarmay S, Alhaj E, Manchikalapudi RB, et al. Left ventricular diastolic dysfunction in patients with pulmonary arterial hypertension (PAH). J Card Fail. 2010;16(8):S19. Exclude - Not a full publication.
Dahoui HA, Hayek MN, Nietert PJ, et al. Pulmonary hypertension in children and young adults with sickle cell disease: evidence for familial clustering. Pediatr Blood Cancer. 2010;54(3):398-402. Exclude - No comparisons of interest. [pmid: 19827138].
D’Alto M, Romeo E, Argiento P, et al. Oral bosentan in patients with congenital heart disease related pulmonary hypertenion and PWP >15 mm HG: Safety, tolerability, clincial, and haemodynamic impact. Chest. 2011;140(4). Exclude - Not a full publication.
D’Alto M, Romeo E, Argiento P, et al. Survival and predictors of death in eisenmenger syndrome. Chest. 2011;140(4). Exclude - Not a full publication.
D’Alto M, Romeo E, Argiento P, et al. Therapy for pulmonary arterial hypertension due to congenital heart disease and Down’s syndrome. Int J Cardiol. 2011. Exclude - No comparisons of interest. [pmid: 21802156].
D’Alto M, Romeo E, Argiento P, et al. Pulmonary vasoreactivity predicts long-term outcome in patients with Eisenmenger syndrome receiving bosentan therapy. Heart. 2010;96(18):1475-9. Exclude - Does not include intervention of interest. [pmid: 20668108].
D’Alto M, Romeo E, Argiento P, et al. Safety, tolerability, clinical and haemodynamic impact of oral bosentan in patients with congenital heart disease related pulmonary hypertension or Eisenmenger syndrome and PWP >15 mmHg. Eur Heart J. 2011;32:113. Exclude - Not a full publication.
D’Alto M, Vizza CD, Romeo E, et al. Long term effects of bosentan treatment in adult patients with pulmonary arterial hypertension related to congenital heart disease (Eisenmenger physiology): safety, tolerability, clinical, and haemodynamic effect. Heart. 2007;93(5):621-5. Exclude - No comparisons of interest. [pmid: 17135220].
Damas JK, Otterdal K, Yndestad A, et al. Soluble CD40 ligand in pulmonary arterial hypertension: possible pathogenic role of the interaction between platelets and endothelial cells. Circulation. 2004;110(8):999-1005. Exclude - No comparisons of interest. [pmid: 15302794].
Dambrauskaite V, Delcroix M, Claus P, et al. Regional right ventricular dysfunction in chronic pulmonary hypertension. J Am Soc Echocardiogr. 2007;20(10):1172-80. Exclude - No comparisons of interest. [pmid: 17570637].
Dambrauskaite V, Delcroix M, Claus P, et al. The evaluation of pulmonary hypertension using right ventricular myocardial isovolumic relaxation time. J Am Soc Echocardiogr. 2005;18(11):1113-20. Exclude - No comparisons of interest. [pmid: 16275518].
Dandekar PG, Verma Y. Efficacy and safety profile of phosphodiestrase 5 inhibitor sildenafil in pulmonary hypertension. European Heart Journal, Supplement. 2012;14:A7. Exclude - Not a full publication.
Dandel M, Kemper D, Weng Y, et al. Primary pulmonary hypertension: survival benefits of therapy with prostacyclin analogs and transplantation. Transplant Proc. 2003;35(6):2117-20. Exclude - No comparisons of interest. [pmid: 14529860].
Dandel M, Lehmkuhl HB, Mulahasanovic S, et al. Survival of patients with idiopathic pulmonary arterial hypertension after listing for transplantation: impact of iloprost and bosentan treatment. J Heart Lung Transplant. 2007;26(9):898-906. Exclude - No comparisons of interest. [pmid: 17845928].
Date H, Kusano KF, Matsubara H, et al. Living-donor lobar lung transplantation for pulmonary arterial hypertension after failure of epoprostenol therapy. J Am Coll Cardiol. 2007;50(6):523-7. Exclude - No comparisons of interest. [pmid: 17678735].
Davarpanah AH, Hodnett PA, Farrelly CT, et al. MDCT bolus tracking data as an adjunct for predicting the diagnosis of pulmonary hypertension and concomitant right-heart failure. AJR Am J Roentgenol. 2011;197(5):1064-72. Exclude - Does not include intervention of interest. [pmid: 22021497].
Dawson JK, Goodson NG, Graham DR, et al. Raised pulmonary artery pressures measured with Doppler echocardiography in rheumatoid arthritis patients. Rheumatology (Oxford). 2000;39(12):1320-5. Exclude - No comparisons of interest. [pmid: 11136873].
de Azevedo AB, Sampaio-Barros PD, Torres RM, et al. Prevalence of pulmonary hypertension in systemic sclerosis. Clin Exp Rheumatol. 2005;23(4):447-54. Exclude - No comparisons of interest. [pmid: 16095111].
De Castro LM, Jonassaint JC, Graham FL, et al. Pulmonary hypertension associated with sickle cell disease: clinical and laboratory endpoints and disease outcomes. Am J Hematol. 2008;83(1):19-25. Exclude - Does not include intervention of interest. [pmid: 17724699].
De Castro S, Cavarretta E, Milan A, et al. Usefulness of tricuspid annular velocity in identifying global RV dysfunction in patients with primary pulmonary hypertension: a comparison with 3D echo-derived right ventricular ejection fraction. Echocardiography. 2008;25(3):289-93. Exclude - No comparisons of interest. [pmid: 18307442].
De Chiara B, Moreo A, Musca F, et al. Assessment of pulmonary arterial pressure during exercise-Doppler echocardiography in systemic sclerosis. Eur Heart J. 2011;32:439. Exclude - Not a full publication.
de Groote P, Gressin V, Hachulla E, et al. Evaluation of cardiac abnormalities by Doppler echocardiography in a large nationwide multicentric cohort of patients with systemic sclerosis. Ann Rheum Dis. 2008;67(1):31-6. Exclude - No comparisons of interest. [pmid: 17267515].
De Jaegere AP, van den Anker JN. Endotracheal instillation of prostacyclin in preterm infants with persistent pulmonary hypertension. Eur Respir J. 1998;12(4):932-4. Exclude - No comparisons of interest. [pmid: 9817171].
De Macedo TB, Braz AS, Anti SMA, et al. Echocardigraphic evaluation in systemic lupus erythematosus: A cross-sectional study of 35 patients. Rev Bras Reumatol. 2000;40(3):97-104. Exclude - Not available in English.
De Pietri L, Montalti R, Begliomini B, et al. Pulmonary hypertension as a predictor of postoperative complications and mortality after liver transplantation. Transplant Proc. 2010;42(4):1188-90. Exclude - No comparisons of interest. [pmid: 20534257].
De Santo LS, Mastroianni C, Romano G, et al. Role of sildenafil in acute posttransplant right ventricular dysfunction: successful experience in 13 consecutive patients. Transplant Proc. 2008;40(6):2015-8. Exclude - No study population of interest. [pmid: 18675118].
De Wet CJ, Affleck DG, Jacobsohn E, et al. Inhaled prostacyclin is safe, effective, and affordable in patients with pulmonary hypertension, right heart dysfunction, and refractory hypoxemia after cardiothoracic surgery. J Thorac Cardiovasc Surg. 2004;127(4):1058-67. Exclude - No study population of interest. [pmid: 15052203].
Degano B, Yaici A, Le Pavec J, et al. Long-term effects of bosentan in patients with HIV-associated pulmonary arterial hypertension. Eur Respir J. 2009;33(1):92-8. Exclude - No comparisons of interest. [pmid: 18799506].
Della Rossa A, Casigliani S, D’Ascanio A, et al. Is NT-probnp a marker of vascular burden in SSc?. Rheumatology (Oxford). 2012;51:ii101. Exclude - Not a full publication.
Demoncheaux EA, Higenbottam TW, Kiely DG, et al. Decreased whole body endogenous nitric oxide production in patients with primary pulmonary hypertension. J Vasc Res. 2005;42(2):133-6. Exclude - No comparisons of interest. [pmid: 15665548].
Denton CP, Pope JE, Peter HH, et al. Long-term effects of bosentan on quality of life, survival, safety and tolerability in pulmonary arterial hypertension related to connective tissue diseases. Ann Rheum Dis. 2008;67(9):1222-8. Exclude - No comparisons of interest. [pmid: 18055477].
Derchi G, Forni GL, Formisano F, et al. Efficacy and safety of sildenafil in the treatment of severe pulmonary hypertension in patients with hemoglobinopathies. Haematologica. 2005;90(4):452-8. Exclude - No comparisons of interest. [pmid: 15820939].
Desai PC, May R, Jones S, et al. Longitudinal study of echocardiographically-derived tricuspid regurgitant jet velocity in sickle cell disease. Blood. 2011;118(21). Exclude - Not a full publication.
Desai PC, May R, Jones SK, et al. Longitudinal study of echocardiographically-derived tricuspid regurgitant jet velocity in sickle cell disease. Am J Hematol. 2011;86(10):E11-E12. Exclude - Not a full publication.
Detterich J, Noetzli L, Carson S, et al. Pulmonary hypertension is uncommon in well-transfused thalassemia major patients. Blood. 2010;116(21). Exclude - Not a full publication.
Devaraj A, Wells AU, Meister MG, et al. Detection of pulmonary hypertension with multidetector CT and echocardiography alone and in combination. Radiology. 2010;254(2):609-16. Exclude - No comparisons of interest. [pmid: 20093532].
Dham N, Ensing G, Minniti C, et al. Prospective echocardiography assessment of pulmonary hypertension and its potential etiologies in children with sickle cell disease. Am J Cardiol. 2009;104(5):713-20. Exclude - No comparisons of interest. [pmid: 19699350].
Diaz-Guzman E, Heresi GA, Dweik RA, et al. Long-term experience after transition from parenteral prostanoids to oral agents in patients with pulmonary hypertension. Respir Med. 2008;102(5):681-9. Exclude - No comparisons of interest. [pmid: 18280130].
Dickinson MG, Scholvinck EH, Boonstra A, et al. Low complication rates with totally implantable access port use in epoprostenol treatment of pulmonary hypertension. J Heart Lung Transplant. 2009;28(3):273-9. Exclude - No comparisons of interest. [pmid: 19285620].
Diller GP, Dimopoulos K, Kaya MG, et al. Long-term safety, tolerability and efficacy of bosentan in adults with pulmonary arterial hypertension associated with congenital heart disease. Heart. 2007;93(8):974-6. Exclude - No comparisons of interest. [pmid: 17639112].
Diller GP, van Eijl S, Okonko DO, et al. Circulating endothelial progenitor cells in patients with Eisenmenger syndrome and idiopathic pulmonary arterial hypertension. Circulation. 2008;117(23):3020-30. Exclude - No comparisons of interest. [pmid: 18519847].
Dimitroulas T, Giannakoulas G, Dimitroula H, et al. Significance of serum uric acid in pulmonary hypertension due to systemic sclerosis: a pilot study. Rheumatol Int. 2011;31(2):263-7. Exclude - No comparisons of interest. [pmid: 20658290].
Dimitroulas T, Giannakoulas G, Karvounis H, et al. Neurohormonal activation in patients with systemic sclerosis-related pulmonary arterial hypertension. Int J Cardiol. 2007;121(1):135-7. Exclude - Not a full publication. [pmid: 17088004].
Dimitroulas T, Giannakoulas G, Papadopoulou K, et al. Left atrial volume and N-terminal pro-B type natriuretic peptide are associated with elevated pulmonary artery pressure in patients with systemic sclerosis. Clin Rheumatol. 2010;29(9):957-64. Exclude - No comparisons of interest. [pmid: 20526641].
Dimitroulas T, Giannakoulas G, Sfetsios T, et al. Asymmetrical dimethylarginine in systemic sclerosis-related pulmonary arterial hypertension. Rheumatology (Oxford). 2008;47(11):1682-5. Exclude - No comparisons of interest. [pmid: 18753191].
Dimopoulos K, Inuzuka R, Goletto S, et al. Improved survival among patients with Eisenmenger syndrome receiving advanced therapy for pulmonary arterial hypertension. Circulation. 2010;121(1):20-5. Exclude - No comparisons of interest. [pmid: 20026774].
Ding J, Ma G, Huang Y, et al. Atrial natriuretic peptide and three-dimensional echocardiography after transcatheter closure of atrial septal defect. Cardiovasc Ultrasound. 2008;6. Exclude - no primary or secondary outcomes of interest.
Dinh Xuan AT, Higenbottam TW, Scott JP, et al. Comparative effects of long-term treatment with prostacyclin and its analogue, iloprost, on exercise tolerance of patients with primary pulmonary hypertension. Eur J Pharmacol. 1990;183(2):527-528. Exclude – not a full publication.
Doe Z, Fukumoto Y, Takaki A, et al. Evidence for Rho-kinase activation in patients with pulmonary arterial hypertension. Circ J. 2009;73(9):1731-9. Exclude - No comparisons of interest. [pmid: 19590140].
Dogan Y, Soylu A, Kilickesmez O, et al. The value of hepatic diffusion-weighted MR imaging in demonstrating hepatic congestion secondary to pulmonary hypertension. Cardiovasc Ultrasound. 2010;8:28. Exclude - Does not include intervention of interest. [pmid: 20663149].
Dollberg S, Warner BW, Myatt L. Urinary nitrite and nitrate concentrations in patients with idiopathic persistent pulmonary hypertension of the newborn and effect of extracorporeal membrane oxygenation. Pediatr Res. 1995;37(1):31-4. Exclude - No comparisons of interest. [pmid: 7700731].
Dong MF, Ma ZS, Ma SJ, et al. Effect of Prostaglandin E1 on Pulmonary Arterial Hypertension Following Corrective Surgery for Congenital Heart Disease. J Cardiovasc Pharmacol Ther. 2011. Exclude - Does not include intervention of interest. [pmid: 22203134].
Douwes JM, van Loon RL, Hoendermis ES, et al. Acute pulmonary vasodilator response in paediatric and adult pulmonary arterial hypertension: occurrence and prognostic value when comparing three response criteria. Eur Heart J. 2011;32(24):3137-46. Exclude - Does not include intervention of interest. [pmid: 21893489].
Droste AS, Rohde D, Voelkers M, et al. Endothelin receptor antagonist and airway dysfunction in pulmonary arterial hypertension. Respir Res. 2009;10:129. Exclude - No comparisons of interest. [pmid: 20042085].
Du ZD, Roguin N, Milgram E, et al. Pulmonary hypertension in patients with thalassemia major. Am Heart J. 1997;134(3):532-7. Exclude - No comparisons of interest. [pmid: 9327712].
Duffels M, van Loon L, Berger R, et al. Pulmonary arterial hypertension associated with a congenital heart defect: advanced medium-term medical treatment stabilizes clinical condition. Congenit Heart Dis. 2007;2(4):242-9. Exclude - No comparisons of interest. [pmid: 18377475].
Duffels MG, Hardziyenka M, Surie S, et al. Duration of right ventricular contraction predicts the efficacy of bosentan treatment in patients with pulmonary hypertension. Eur J Echocardiogr. 2009;10(3):433-8. Exclude - Does not include intervention of interest. [pmid: 19042941].
Duffels MG, van der Plas MN, Surie S, et al. Bosentan in pulmonary arterial hypertension: a comparison between congenital heart disease and chronic pulmonary embolism. Neth Heart J. 2009;17(9):334-8. Exclude - No comparisons of interest. [pmid: 19949475].
Duffels MG, Vis JC, van Loon RL, et al. Effect of bosentan on exercise capacity and quality of life in adults with pulmonary arterial hypertension associated with congenital heart disease with and without Down’s syndrome. Am J Cardiol. 2009;103(9):1309-15. Exclude - No comparisons of interest. [pmid: 19406277].
Duffels MGJ, Berger RMF, Bresser P, et al. Applicability of bosentan in Dutch patients with Eisenmenger syndrome: Preliminary results on safety and exercise capacity. Neth Heart J. 2006;14(5):165-170. Exclude - No comparisons of interest.
Dulac Y, Acar P. Pharmacokinetic and clinical profile of a novel formulation of bosentan in children with pulmonary arterial hypertension: The FUTURE-1 study. Arch Cardiovasc Dis. 2010;2(2):146-152. Exclude - Not available in English.
Dumitrescu A, Walsh KP. Eisenmenger syndrome - Conventional management and new therapeutic prospects. Br J Cardiol. 2006;13(6):419-424. Exclude - Not a full publication.
Dumitrescu D, Seck C, Moinzadeh P, et al. Relevance of exercise gas exchange in different stages of scleroderma-associated pulmonary arterial hypertension - Comparison with resting echocardiography. Eur Heart J. 2011;32:439. Exclude - Not a full publication.
Dupuis J, Cernacek P, Tardif JC, et al. Reduced pulmonary clearance of endothelin-1 in pulmonary hypertension. Am Heart J. 1998;135(4):614-20. Exclude - Does not include intervention of interest. [pmid: 9539476].
Durongpisitkul K, Jakrapanichakul D, Laohaprasitiporn D, et al. Combination therapy of prostacyclin for pulmonary hypertension in congenital heart disease. J Med Assoc Thai. Suppl 8. 2005;88:S60-5. Exclude - No comparisons of interest. [pmid: 16856428].
Durongpisitkul K, Jakrapanichakul D, Sompradikul S. A retrospective study of bosentan in pulmonary arterial hypertension associated with congenital heart disease. J Med Assoc Thai. 2008;91(2):196-202. Exclude - No comparisons of interest. [pmid: 18389984].
Durongpisitkul K, Pornrattanarungsi S, Panjasamanvong P, et al. Efficacy and safety of high dose generic sildenafil in Thai patients with pulmonary arterial hypertension. J Med Assoc Thai. 2011;94(4):421-6. Exclude - No comparisons of interest. [pmid: 21591526].
Dyer K, Lanning C, Das B, et al. Noninvasive Doppler tissue measurement of pulmonary artery compliance in children with pulmonary hypertension. J Am Soc Echocardiogr. 2006;19(4):403-12. Exclude - Does not include intervention of interest. [pmid: 16581479].
Eddahibi S, Humbert M, Sediame S, et al. Imbalance between platelet vascular endothelial growth factor and platelet-derived growth factor in pulmonary hypertension. Effect of prostacyclin therapy. Am J Respir Crit Care Med. 2000;162(4 Pt 1):1493-9. Exclude - no primary or secondary outcomes of interest. [pmid: 11029367].
Eifinger F, Sreeram N, Mehler K, et al. Aerosolized iloprost in the treatment of pulmonary hypertension in extremely preterm infants: a pilot study. Klin Padiatr. 2008;220(2):66-9. Exclude - No comparisons of interest. [pmid: 17710738].
Einarson TR, Granton JT, Vicente C, et al. Cost-effectiveness of treprostinil versus epoprostenol in patients with pulmonary arterial hypertension: a Canadian analysis. Can Respir J. 2005;12(8):419-25. Exclude - no primary or secondary outcomes of interest. [pmid: 16331313].
El-Beshlawy A, Youssry I, El-Saidi S, et al. Pulmonary hypertension in beta-thalassemia major and the role of L-carnitine therapy. Pediatr Hematol Oncol. 2008;25(8):734-43. Exclude - No comparisons of interest. [pmid: 19065439].
Elnoamany MF, Dawood A, Khalil T, et al. Reliability of right ventricular myocardial isovolumic relaxation time as a predictor of pulmonary hypertension. Eur Heart J. 2011;32:1019. Exclude - Not a full publication.
Elstein D, Klutstein MW, Lahad A, et al. Echocardiographic assessment of pulmonary hypertension in Gaucher’s disease. Lancet. 1998;351(9115):1544-6. Exclude - No comparisons of interest. [pmid: 10326537].
Elstein D, Nir A, Klutstein M, et al. C-reactive protein and NT-proBNP as surrogate markers for pulmonary hypertension in Gaucher disease. Blood Cells Mol Dis. 2005;34(3):201-5. Exclude - No comparisons of interest. [pmid: 15885602].
Er F, Ederer S, Nia AM, et al. Accuracy of Doppler-echocardiographic mean pulmonary artery pressure for diagnosis of pulmonary hypertension. PLoS One. 2010;5(12):e15670. Exclude - No study population of interest. [pmid: 21179417].
Eronen M, Pohjavuori M, Andersson S, et al. Prostacyclin treatment for persistent pulmonary hypertension of the newborn. Pediatr Cardiol. 1997;18(1):3-7. Exclude - No comparisons of interest. [pmid: 8960484].
Espinola-Zavaleta N, Vargas-Barron J, Tazar JI, et al. Echocardiographic Evaluation of Patients with Primary Pulmonary Hypertension Before and After Atrial Septostomy. Echocardiography. 1999;16(7, Pt 1):625-634. Exclude - no primary or secondary outcomes of interest. [pmid: 11175203].
Espinosa Martinez E, Garcia Caraballoso MB, Espinosa Estrada EE, et al. Pulmonary hypertension in adults with sickle cell anemia. Preliminary results. Rev Cuba Hematol Imunol Hemoterapia. 2010;26(3):206-215. Exclude - Not available in English.
Evans N, Kluckow M, Currie A. Range of echocardiographic findings in term neonates with high oxygen requirements. Arch Dis Child Fetal Neonatal Ed. 1998;78(2):F105-11. Exclude - No study population of interest. [pmid: 9577279].
Ewert R, Opitz C, Wensel R, et al. Iloprost as inhalative or intravenous long-term treatment of patients with primary pulmonary hypertension. Register of the Berlin Study Group for Pulmonary Hypertension Z Kardiol. 2000;89(11):987-999. Exclude - Not available in English.
Ewert R, Opitz CF, Wensel R, et al. Continuous intravenous iloprost to revert treatment failure of first-line inhaled iloprost therapy in patients with idiopathic pulmonary arterial hypertension. Clin Res Cardiol. 2007;96(4):211-7. Exclude - No comparisons of interest. [pmid: 17294349].
Eysmann SB, Palevsky HI, Reichek N, et al. Echo/Doppler and hemodynamic correlates of vasodilator responsiveness in primary pulmonary hypertension. Chest. 1991;99(5):1066-71. Exclude – no primary or secondary outcomes of interest. [pmid: 2019158].
Fasnacht MS, Tolsa JF, Beghetti M. The Swiss registry for pulmonary arterial hypertension: the paediatric experience. Swiss Med Wkly. 2007;137(35–36):510-3. Exclude - Not a full publication. [pmid: 17990138].
Ferlinz J. Right ventricular diastolic performance: compliance characteristics with focus on pulmonary hypertension, right ventricular hypertrophy, and calcium channel blockade. Cathet Cardiovasc Diagn. 1998;43(2):206-43. Exclude - Not a full publication. [pmid: 9488559].
Fernandes CJ, Dias BA, Jardim CV, et al. The role of target therapies in schistosomiasis-associated pulmonary arterial hypertension. Chest. 2012;141(4):923-8. Exclude - No comparisons of interest. [pmid: 22030800].
Fernandez A, Simeon CP, Fonollosa V, et al. Clinical, epidemiological and haemodynamic differences between idiopathic and scleroderma-related pulmonary arterial hypertension. Rheumatology (Oxford). 2012;51:ii97-ii98. Exclude - Not a full publication.
Fields A, Roberts J, Forfia P. Pulmonary hypertension specific therapy improves cardiac structure and function without detectable changes in doppler pa systolic pressure in patients with pulmonary arterial hypertension. Chest. 2011;140(4). Exclude - Not a full publication.
Fields A, Roberts J, Forfia P. Serial tapse at 1 year, not baseline tapse, predicts survival differences in patients with an incident diagnosis of pulmonary arterial hypertension. Chest. 2011;140(4). Exclude - Not a full publication.
Fields AV, Sinha SS, Saggar R, et al. Simple echo-Doppler tool powerfully predicts response to pulmonary hypertension specific therapy in WHO Group 3 pulmonary hypertension. J Heart Lung Transplant. 2012;31(4):S212. Exclude - Not a full publication.
Filusch A, Mereles D, Gruenig E, et al. Strain and strain rate echocardiography for evaluation of right ventricular dysfunction in patients with idiopathic pulmonary arterial hypertension. Clin Res Cardiol. 2010;99(8):491-8. Exclude - Does not include intervention of interest. [pmid: 20352437].
Filusch A, Zelniker T, Baumgartner C, et al. Soluble TWEAK predicts hemodynamic impairment and functional capacity in patients with pulmonary arterial hypertension. Clin Res Cardiol. 2011;100(10):879-85. Exclude - Does not include intervention of interest. [pmid: 21479966].
Finazzi S, Vicenzi E, Faggioli P, et al. NT-proBNP in systemic sclerosis-related pulmonary arterial hypertension. Riv Ital Med Labor. 2006;2(3):224-228. Exclude - Not available in English.
Fisher EA, Ruden R. Pulmonary artery pressures and valvular lesions in patients taking diet suppressants. Cardiovasc Rev Rep. 1998;19(4):13-16. Exclude - No comparisons of interest.
Flattery MP, Pinson JM, Savage L, et al. Living with pulmonary artery hypertension: patients’ experiences. Heart Lung. 2005;34(2):99-107. Exclude - Does not include intervention of interest. [pmid: 15761454].
Flox-Camacho A, Escribano-Subias P, Jimenez-Lopez Guarch C, et al. Factors affecting the response to exercise in patients with severe pulmonary arterial hypertension. Arch Bronconeumol. 2011;47(1):10-6. Exclude - no primary or secondary outcomes of interest. [pmid: 20889250].
Fois E, Le Guern V, Dupuy A, et al. Noninvasive assessment of systolic pulmonary artery pressure in systemic lupus erythematosus: retrospective analysis of 93 patients. Clin Exp Rheumatol. 2010;28(6):836-41. Exclude - No comparisons of interest. [pmid: 21205461].
Foley RJ, Wilcox D, Walsh SJ, et al. Survival of geriatric idiopathic pulmonary arterial hypertension patients. Conn Med. 2011;75(1):11-5. Exclude - Does not include intervention of interest. [pmid: 21329286].
Ford HJ, Aris RM, Andreoni K. Screening for portopulmonary hypertension with transthoracic echocardiography: implications for early mortality associated with liver transplantation. Am J Respir Crit Care Med. 2009;180(4):378. author reply 378–9. Exclude - Not a full publication. [pmid: 19661254].
Forrest IA, Small T, Corris PA. Effect of nebulized epoprostenol (prostacyclin) on exhaled nitric oxide in patients with pulmonary hypertension due to congenital heart disease and in normal controls. Clin Sci (Lond). 1999;97(1):99-102. Exclude - no primary or secondary outcomes of interest. [pmid: 10369800].
Forrest S, Kim A, Carbonella J, et al. Proteinuria is associated with elevated tricuspid regurgitant jet velocity in children with sickle cell disease. Pediatr Blood Cancer. 2012;58(6):937-40. Exclude - Does not include intervention of interest. [pmid: 21990235].
Forrest SJ, Pashankar FD. Pulmonary hypertension and proteinuria in children with sickle cell disease. Am J Hematol. 2011;86(10):E21. Exclude - Not a full publication.
Fox BD, Kassirer M, Weiss I, et al. Ambulatory rehabilitation improves exercise capacity in patients with pulmonary hypertension. J Card Fail. 2011;17(3):196-200. Exclude - Does not include intervention of interest. [pmid: 21362526].
Fraisse A, Butrous G, Taylor MB, et al. Intravenous sildenafil for postoperative pulmonary hypertension in children with congenital heart disease. Intensive Care Med. 2011;37(3):502-9. Exclude - no primary or secondary outcomes of interest. [pmid: 21069290].
Fraisse A, Geva T, Gaudart J, et al. Doppler echocardiographic predictors of outcome in newborns with persistent pulmonary hypertension. Cardiol Young. 2004;14(3):277-83. Exclude - Does not include intervention of interest. [pmid: 15680021].
Fraisse A, Jais X, Schleich JM, et al. Characteristics and prospective two-year follow-up of children with pulmonary arterial hypertension in France. Arch Cardiovasc Dis. 2010;2(2):137-145. Exclude - Not available in English.
Frantz RP, Benza RL, Kjellstrom B, et al. Continuous hemodynamic monitoring in patients with pulmonary arterial hypertension. J Heart Lung Transplant. 2008;27(7):780-8. Exclude - Does not include intervention of interest. [pmid: 18582809].
Friedberg MK, Feinstein JA, Rosenthal DN. Noninvasive assessment of pulmonary arterial capacitance by echocardiography. J Am Soc Echocardiogr. 2007;20(2):186-90. Exclude - Does not include intervention of interest. [pmid: 17275705].
Friedman D, Szmuszkovicz J, Rabai M, et al. Systemic endothelial dysfunction in children with idiopathic pulmonary arterial hypertension correlates with disease severity. J Heart Lung Transplant. 2012;31(6):642-647. Exclude - Does not include intervention of interest. [pmid: 22440720].
Friedman R, Mears JG, Barst RJ. Continuous infusion of prostacyclin normalizes plasma markers of endothelial cell injury and platelet aggregation in primary pulmonary hypertension. Circulation. 1997;96(9):2782-4. Exclude - no primary or secondary outcomes of interest. [pmid: 9386137].
Fruchter O, Yigla M. Underlying aetiology of pulmonary hypertension in 191 patients: a single centre experience. Respirology. 2008;13(6):825-31. Exclude - no primary or secondary outcomes of interest. [pmid: 18811881].
Fruhwald FM, Kjellstrom B, Perthold W, et al. Continuous hemodynamic monitoring in pulmonary hypertensive patients treated with inhaled iloprost. Chest. 2003;124(1):351-9. Exclude - No comparisons of interest. [pmid: 12853544].
Funauchi M, Kishimoto K, Shimazu H, et al. Effects of bosentan on the skin lesions: an observational study from a single center in Japan. Rheumatol Int. 2009;29(7):769-75. Exclude - No comparisons of interest. [pmid: 19037604].
Furuya Y, Kuwana M. Effect of bosentan on systemic sclerosis-associated interstitial lung disease ineligible for cyclophosphamide therapy: A prospective open-label study. J Rheumatol. 2011;38(10):2186-2192. Exclude - No study population of interest. [pmid: 21885489].
Gabler NB, French B, Strom BL, et al. Race and sex differences in response to endothelin receptor antagonists for pulmonary arterial hypertension. Chest. 2012;141(1):20-6. Exclude - Background SR/MA. [pmid: 21940766].
Gabrielli LA, Castro PF, Godoy I, et al. Systemic oxidative stress and endothelial dysfunction is associated with an attenuated acute vascular response to inhaled prostanoid in pulmonary artery hypertension patients. J Card Fail. 2011;17(12):1012-7. Exclude - no primary or secondary outcomes of interest. [pmid: 22123364].
Galie N, Badesch D, Oudiz R, et al. Ambrisentan therapy for pulmonary arterial hypertension. J Am Coll Cardiol. 2005;46(3):529-35. Exclude - No comparisons of interest. [pmid: 16053970].
Galie N, Barst R, Brundage B, et al. Long-term outcomes of patients with pulmonary arterial hypertension associated with connective tissue disease as compared with idiopathic or heritable pulmonary arterial hypertension treated with tadalafil. Chest. 2011;140(4). Exclude - Not a full publication.
Galie N, Humbert M, Vachiery JL, et al. Effects of beraprost sodium, an oral prostacyclin analogue, in patients with pulmonary arterial hypertension: a randomized, double-blind, placebo-controlled trial. J Am Coll Cardiol. 2002;39(9):1496-502. Exclude - Does not include intervention of interest. [pmid: 11985913].
Gan CT, Holverda S, Marcus JT, et al. Right ventricular diastolic dysfunction and the acute effects of sildenafil in pulmonary hypertension patients. Chest. 2007;132(1):11-7. Exclude - No comparisons of interest. [pmid: 17625080].
Garg N, Sharma MK, Sinha N. Role of oral sildenafil in severe pulmonary arterial hypertension: clinical efficacy and dose response relationship. Int J Cardiol. 2007;120(3):306-13. Exclude - No comparisons of interest. [pmid: 17174417].
Garg N, Tripathy N, Sinha N. Comparative efficacy of sildenafil in Eisenmenger’s syndrome secondary to atrial septal defect versus ventricular septal defect: A cardiac catheterisation follow-up study. Cardiol Young. 2011;21(6):637-638. Exclude - No comparisons of interest.
Garin MC, Clark L, Chumney EC, et al. Cost-utility of treatments for pulmonary arterial hypertension: a Markov state-transition decision analysis model. Clin Drug Investig. 2009;29(10):635-46. Exclude - no primary or secondary outcomes of interest. [pmid: 19715380].
Garypidou V, Vakalopoulou S, Dimitriadis D, et al. Incidence of pulmonary hypertension in patients with chronic myeloproliferative disorders. Haematologica. 2004;89(2):245-6. Exclude - Not a full publication. [pmid: 15003906].
Generali J, Cada DJ. Tadalafil: Pulmonary hypertension (adults). Hosp Pharm. 2005;40(3):225-232. Exclude - Not a full publication.
Gessler T, Schmehl T, Hoeper MM, et al. Ultrasonic versus jet nebulization of iloprost in severe pulmonary hypertension. Eur Respir J. 2001;17(1):14-9. Exclude - No comparisons of interest. [pmid: 11307743].
Ghayumi SMA, Mehrabi S, Zamirian M, et al. Pulmonary complications in cirrhotic candidates for liver transplantation. Hepatitis Mon. 2010;10(2):105-109. Exclude - No comparisons of interest.
Ghio S, Pazzano AS, Klersy C, et al. Clinical and prognostic relevance of echocardiographic evaluation of right ventricular geometry in patients with idiopathic pulmonary arterial hypertension. Am J Cardiol. 2011;107(4):628-32. Exclude - Does not include intervention of interest. [pmid: 21184990].
Ghofrani HA, Friese G, Discher T, et al. Inhaled iloprost is a potent acute pulmonary vasodilator in HIV-related severe pulmonary hypertension. Eur Respir J. 2004;23(2):321-6. Exclude - No comparisons of interest. [pmid: 14979511].
Ghofrani HA, Grimminger F. Modulating cGMP to treat lung diseases. Handb Exp Pharmacol. 2009;191:469-483. Exclude - Background Other. [pmid: 19089341].
Ghofrani HA, Rose F, Schermuly RT, et al. Oral sildenafil as long-term adjunct therapy to inhaled iloprost in severe pulmonary arterial hypertension. J Am Coll Cardiol. 2003;42(1):158-64. Exclude - No comparisons of interest. [pmid: 12849677].
Ghofrani HA, Rose F, Schermuly RT, et al. Amplification of the pulmonary vasodilatory response to inhaled iloprost by subthreshold phosphodiesterase types 3 and 4 inhibition in severe pulmonary hypertension. Crit Care Med. 2002;30(11):2489-92. Exclude - No comparisons of interest. [pmid: 12441759].
Ghofrani HA, Schermuly RT, Rose F, et al. Sildenafil for long-term treatment of nonoperable chronic thromboembolic pulmonary hypertension. Am J Respir Crit Care Med. 2003;167(8):1139-41. Exclude - No study population of interest. [pmid: 12684251].
Ghofrani HA, Voswinckel R, Reichenberger F, et al. Differences in hemodynamic and oxygenation responses to three different phosphodiesterase-5 inhibitors in patients with pulmonary arterial hypertension: a randomized prospective study. J Am Coll Cardiol. 2004;44(7):1488-96. Exclude - no primary or secondary outcomes of interest. [pmid: 15464333].
Ghofrani HA, Wiedemann R, Rose F, et al. Combination therapy with oral sildenafil and inhaled iloprost for severe pulmonary hypertension. Ann Intern Med. 2002;136(7):515-22. Exclude - no primary or secondary outcomes of interest. [pmid: 11926786].
Ghosh K, Meera V, Jijina F. Pulmonary hypertension in patients with hematological disorders following splenectomy. Indian J Hematol Blood Transfus. 2009;25(2):45-48. Exclude - no primary or secondary outcomes of interest. [pmid: 23100974].
Giannelli G, Iannone F, Marinosci F, et al. The effect of bosentan on matrix metalloproteinase-9 levels in patients with systemic sclerosis-induced pulmonary hypertension. Curr Med Res Opin. 2005;21(3):327-32. Exclude - No comparisons of interest. [pmid: 15811199].
Giannelli G, Iannone F, Marinosci F, et al. Clinical outcomes of bosentan in pulmonary arterial hypertension do not correlate with levels of TIMPs. Eur J Clin Invest. Suppl 3. 2006;36:73-7. Exclude - Does not include intervention of interest. [pmid: 16919016].
Gilbert C, Brown MC, Cappelleri JC, et al. Estimating a minimally important difference in pulmonary arterial hypertension following treatment with sildenafil. Chest. 2009;135(1):137-42. Exclude - no primary or secondary outcomes of interest. [pmid: 18812447].
Gilbert N, Luther YC, Miera O, et al. Initial experience with bosentan (Tracleer) as treatment for pulmonary arterial hypertension (PAH) due to congenital heart disease in infants and young children. Z Kardiol. 2005;94(9):570-4. Exclude - No comparisons of interest. [pmid: 16142516].
Gildein HP, Wildberg A, Mocellin R. Comparison of the effect of prostacyclin and nifedipine on the hemodynamics in patients with Eisenmenger syndrome. Z Kardiol. 1995;84(1):55-63. Exclude - Not available in English. [pmid: 7863716].
Gindzienska-Sieskiewicz E, Kowal-Bielecka O, Kita J, et al. The occurrence of pulmonary hypertension in patients with systemic sclerosis hospitalized in the Department of Rheumatology and Internal Diseases Medical University of Bialystok in years 2003–2004. Rocz Akad Med Bialymst. Suppl 1. 2005;50:297-300. Exclude - No comparisons of interest. [pmid: 16119691].
Girgis RE, Champion HC, Diette GB, et al. Decreased exhaled nitric oxide in pulmonary arterial hypertension: response to bosentan therapy. Am J Respir Crit Care Med. 2005;172(3):352-7. Exclude - no primary or secondary outcomes of interest. [pmid: 15879413].
Girgis RE, Mathai SC, Krishnan JA, et al. Long-term outcome of bosentan treatment in idiopathic pulmonary arterial hypertension and pulmonary arterial hypertension associated with the scleroderma spectrum of diseases. J Heart Lung Transplant. 2005;24(10):1626-31. Exclude - No comparisons of interest. [pmid: 16210140].
Giunta A, Tirri E, Maione S, et al. Right ventricular diastolic abnormalities in systemic sclerosis. Relation to left ventricular involvement and pulmonary hypertension. Ann Rheum Dis. 2000;59(2):94-8. Exclude - No comparisons of interest. [pmid: 10666162].
Gladwin MT. Prevalence, risk factors and mortality of pulmonary hypertension defined by right heart catheterization in patients with sickle cell disease. Expert Rev Hematol. 2011;4(6):593-6. Exclude - Not a full publication. [pmid: 22077523].
Gladwin MT, Barst RJ, Castro OL, et al. Pulmonary hypertension and NO in sickle cell. Blood. 2010;116(5):852-4. Exclude - Not a full publication. [pmid: 20688967].
Gladwin MT, Sachdev V, Jison ML, et al. Pulmonary hypertension as a risk factor for death in patients with sickle cell disease. N Engl J Med. 2004;350(9):886-95. Exclude - No comparisons of interest. [pmid: 14985486].
Gnaneswaran N, Pang B, Gerche AL, et al. Comparison of doppler-derived methods to predict invasive mean pulmonary artery pressure at rest and after exercise in patients with scleroderma. Heart Lung Circul. 2011;20:S164. Exclude - Not a full publication.
Gomberg-Maitland M, McLaughlin V, Gulati M, et al. Efficacy and safety of sildenafil added to treprostinil in pulmonary hypertension. Am J Cardiol. 2005;96(9):1334-6. Exclude - No comparisons of interest. [pmid: 16253609].
Gomberg-Maitland M, Tapson VF, Benza RL, et al. Transition from intravenous epoprostenol to intravenous treprostinil in pulmonary hypertension. Am J Respir Crit Care Med. 2005;172(12):1586-9. Exclude - No comparisons of interest. [pmid: 16151039].
Gomez A, Bialostozky D, Zajarias A, et al. Right ventricular ischemia in patients with primary pulmonary hypertension. J Am Coll Cardiol. 2001;38(4):1137-42. Exclude - No comparisons of interest. [pmid: 11583894].
Goncalvesova E, Luknar M, Lesny P. ECG signs of right ventricular hypertrophy may help distinguish pulmonary arterial hypertension and pulmonary hypertension due to left ventricular diastolic dysfunction. Bratisl Lek Listy. 2011;112(11):614-8. Exclude - Does not include intervention of interest. [pmid: 22180986].
Gonzalez-Juanatey C, Amigo-Diaz E, Miranda-Filloy JA, et al. Lack of echocardiographic and Doppler abnormalities in psoriatic arthritis patients without clinically evident cardiovascular disease or classic atherosclerosis risk factors. Semin Arthritis Rheum. 2006;35(5):333-9. Exclude - No comparisons of interest. [pmid: 16616156].
Gonzalez-Juanatey C, Testa A, Garcia-Castelo A, et al. Echocardiographic and Doppler findings in long-term treated rheumatoid arthritis patients without clinically evident cardiovascular disease. Semin Arthritis Rheum. 2004;33(4):231-8. Exclude - Does not include intervention of interest. [pmid: 14978661].
Gorcsan J 3rd, Edwards TD, Ziady GM, et al. Transesophageal echocardiography to evaluate patients with severe pulmonary hypertension for lung transplantation. Ann Thorac Surg. 1995;59(3):717-22. Exclude - Does not include intervention of interest. [pmid: 7887718].
Gorenflo M, Bettendorf M, Brockmeier K, et al. Pulmonary vasoreactivity and vasoactive mediators in children with pulmonary hypertension. Z Kardiol. 2000;89(11):1000-8. Exclude - no primary or secondary outcomes of interest. [pmid: 11149265].
Gorenflo M, Gu H, Xu Z. Peri-operative pulmonary hypertension in paediatric patients: current strategies in children with congenital heart disease. Cardiology. 2010;116(1):10-7. Exclude - Not a full publication. [pmid: 20424447].
Gorenflo M, Zheng C, Poge A, et al. Metabolites of the L-arginine-NO pathway in patients with left-to-right shunt. Clin Lab. 2001;47(9–10):441-7. Exclude - Does not include intervention of interest. [pmid: 11596905].
Gough MS, White RJ. Sildenafil therapy is associated with improved hemodynamics in liver transplantation candidates with pulmonary arterial hypertension. Liver Transpl. 2009;15(1):30-6. Exclude - No comparisons of interest. [pmid: 19109844].
Graf S, Hakendorf P, Lester S, et al. South Australian scleroderma register: Autoantibodies as predictive biomarkers of phenotype and outcome. Internal Medicine Journal. 2011;41:1. Exclude - Not a full publication.
Grapsa J, Gibbs JS, Dawson D, et al. Morphologic and functional remodeling of the right ventricle in pulmonary hypertension by real time three dimensional echocardiography. Am J Cardiol. 2012;109(6):906-13. Exclude - no primary or secondary outcomes of interest. [pmid: 22196780].
Grapsa J, Gibbs JSR, Cabrita IZ, et al. Clinical outcome and right atrial remodeling in patients with pulmonary arterial hypertension: Study with real time 3D Echocardiography. Eur Heart J. 2011;32:437-438. Exclude - Not a full publication. [pmid: 21118851].
Grapsa J, O’Regan DP, Pavlopoulos H, et al. Right ventricular remodelling in pulmonary arterial hypertension with three-dimensional echocardiography: comparison with cardiac magnetic resonance imaging. Eur J Echocardiogr. 2010;11(1):64-73. Exclude - no primary or secondary outcomes of interest. [pmid: 19939819].
Graul A, Leeson PA, Castaner J. Sitaxsentan sodium. Endothelin ET(A) antagonist treatment of heart failure treatment of pulmonary hypertension. Drugs Future. 2000;25(2):159-164. Exclude - Not a full publication.
Grimminger F, Olschewski H, Rose F, et al. Severe pulmonary hypertension - Vasodilatory treatment of pulmonary flow. Pneumologie. 2000;54(4):160-169. Exclude - Not available in English.
Gruenig E, Michelakis E, Vachiery JL, et al. Acute hemodynamic effects of single-dose sildenafil when added to established bosentan therapy in patients with pulmonary arterial hypertension: results of the COMPASS-1 study. J Clin Pharmacol. 2009;49(11):1343-52. Exclude - No comparisons of interest. [pmid: 19755415].
Grunig E, Janssen B, Mereles D, et al. Abnormal pulmonary artery pressure response in asymptomatic carriers of primary pulmonary hypertension gene. Circulation. 2000;102(10):1145-50. Exclude - Does not include intervention of interest. [pmid: 10973844].
Grunig E, Koehler R, Miltenberger-Miltenyi G, et al. Primary pulmonary hypertension in children may have a different genetic background than in adults. Pediatr Res. 2004;56(4):571-8. Exclude - Does not include intervention of interest. [pmid: 15295086].
Grunig E, Mereles D, Arnold K, et al. Primary pulmonary hypertension is predominantly a hereditary disease. Chest. 8. 2002;121(3 Suppl):1S-82S. Exclude - Not a full publication. [pmid: 11893705].
Grunig E, Weissmann S, Ehlken N, et al. Stress Doppler echocardiography in relatives of patients with idiopathic and familial pulmonary arterial hypertension: results of a multicenter European analysis of pulmonary artery pressure response to exercise and hypoxia. Circulation. 2009;119(13):1747-57. Exclude - No comparisons of interest. [pmid: 19307479].
Guazzi M, Vicenzi M, Arena R, et al. A long term follow-up study of patients with mild to moderate group 2 pulmonary hypertension treated with Pde5-inhibition: A comparison between heart failure with reduced and preserved ejection fraction. Circulation. 2011;124(21). Exclude - Not a full publication.
Gueffet JP, Piriou N, Trochu JN. Valvular heart disease associated with benfluorex. Arch Cardiovasc Dis. 2010;103(5):342-3. Exclude - Not a full publication. [pmid: 20619246].
Gunes Y, Guntekin U, Tuncer M, et al. Association of coronary sinus diameter with pulmonary hypertension. Echocardiography. 2008;25(9):935-40. Exclude - No study population of interest. [pmid: 18771553].
Guntekin U, Gunes Y, Tuncer M, et al. QTc dispersion in hyperthyroidism and its association with pulmonary hypertension. Pacing Clin Electrophysiol. 2009;32(4):494-9. Exclude - No comparisons of interest. [pmid: 19335859].
Guogan W, Baiping C, Hanying L, et al. The alteration of the pulmonary artery flow spectrum with pulmonary hypertension. Chin Med Sci J. 1999;14(4):220-3. Exclude - no primary or secondary outcomes of interest. [pmid: 12894895].
Gupta A, Kerkar P. Sildenafil for pulmonary hypertension secondary to congenital heart diseases. Indian Heart J. 2007;59(4):342-5. Exclude - No comparisons of interest. [pmid: 19126940].
Gupta R, Perumandla S, Patsiornik Y, et al. Incidence of pulmonary hypertension in patients with chronic myeloproliferative disorders. J Natl Med Assoc. 2006;98(11):1779-82. Exclude - No comparisons of interest. [pmid: 17128687].
Gupta U, Abdulla RI, Bokowski J. Benign outcome of pulmonary hypertension in neonates with a restrictive patent foramen ovale versus result for neonates with an unrestrictive patent foramen ovale. Pediatr Cardiol. 2011;32(7):972-6. Exclude - Does not include intervention of interest. [pmid: 21710183].
Gustafsson J, Simard JF, Gunnarsson I, et al. Risk factors for cardiovascular mortality in patients with systemic lupus erythematosus, a prospective cohort study. Arthritis Research & Therapy. 2012:R46. Exclude - Does not include intervention of interest. [pmid: 22390680].
Ha JW, Choi D, Park S, et al. Determinants of exercise-induced pulmonary hypertension in patients with normal left ventricular ejection fraction. Heart. 2009;95(6):490-4. Exclude - Does not include intervention of interest. [pmid: 18653569].
Hache M, Denault A, Belisle S, et al. Inhaled epoprostenol (prostacyclin) and pulmonary hypertension before cardiac surgery. J Thorac Cardiovasc Surg. 2003;125(3):642-9. Exclude - no primary or secondary outcomes of interest. [pmid: 12658208].
Hache M, Denault AY, Belisle S, et al. Inhaled prostacyclin (PGI2) is an effective addition to the treatment of pulmonary hypertension and hypoxia in the operating room and intensive care unit. Can J Anaesth. 2001;48(9):924-9. Exclude - No study population of interest. [pmid: 11606352].
Hachulla E, de Groote P, Gressin V, et al. The three-year incidence of pulmonary arterial hypertension associated with systemic sclerosis in a multicenter nationwide longitudinal study in France. Arthritis Rheum. 2009;60(6):1831-9. Exclude - Does not include intervention of interest. [pmid: 19479881].
Haddad F, Doyle R, Denault AY, et al. Echocardiographic and clinical predictors of outcome in patients with pulmonary arterial hypertension. J Heart Lung Transplant. 2012;31(4):S284. Exclude - Not a full publication.
Haeck ML, Scherptong RW, Marsan NA, et al. Prognostic implications of right ventricular longitudinal peak systolic strain on long-term outcome in patients with pulmonary hypertension. Circulation. 2011;124(21). Exclude - Not a full publication.
Hagan G, Southwood M, Treacy C, et al. Are inflammatory cytokine levels altered by treatment of pulmonary arterial hypertension?. Thorax. 2011;66:A67-A68. Exclude - Not a full publication.
Hagar RW, Michlitsch JG, Gardner J, et al. Clinical differences between children and adults with pulmonary hypertension and sickle cell disease. Br J Haematol. 2008;140(1):104-12. Exclude - Does not include intervention of interest. [pmid: 17916102].
Hahn CH, Kang SM, Moon JW, et al. The Utility of Measurement of Plasma N-terminal Pro-brain Natriuretic Peptide in Diagnosis of Pulmonary Hypertension. Tuberc Respir Dis. 2004;56(1):67-76. Exclude - Not available in English.
Hahn KL. Old drugs are new again. Pharm Times. 2011;77(6). Exclude - Not a full publication.
Hall SM, Davie N, Klein N, et al. Endothelin receptor expression in idiopathic pulmonary arterial hypertension: Effect of bosentan and epoprostenol treatment. Eur Respir J. 2011;38(4):851-860. Exclude - Does not include intervention of interest. [pmid: 21406517].
Hallioglu O, Dilber E, Celiker A. Comparison of acute hemodynamic effects of aerosolized and intravenous iloprost in secondary pulmonary hypertension in children with congenital heart disease. Am J Cardiol. 2003;92(8):1007-9. Exclude - Not a full publication. [pmid: 14556887].
Handa T, Nagai S, Miki S, et al. Incidence of pulmonary hypertension and its clinical relevance in patients with interstitial pneumonias: comparison between idiopathic and collagen vascular disease associated interstitial pneumonias. Intern Med. 2007;46(12):831-7. Exclude - no primary or secondary outcomes of interest. [pmid: 17575374].
Hanna MG, Shaltout FF, El-Fikky MA, et al. Assessment of the role of inhaled nitric oxide and high frequency oscillatory ventilation in persistent pulmonary hypertension of the newborn. Egypt J Anaesth. 2004;20(1):47-52. Exclude - unable to obtain full-text.
Hansmann G, Plouffe BD, Hatch A, et al. Design and validation of an endothelial progenitor cell capture chip and its application in patients with pulmonary arterial hypertension. J Mol Med (Berl). 2011;89(10):971-83. Exclude - Does not include intervention of interest. [pmid: 21735044].
Haque AK, Gokhale S, Rampy BA, et al. Pulmonary hypertension in sickle cell hemoglobinopathy: a clinicopathologic study of 20 cases. Hum Pathol. 2002;33(10):1037-43. Exclude - No comparisons of interest. [pmid: 12395378].
Hardegree E, Sachdev A, Villarraga H, et al. Prognostic significance of ventricular interdependence in right ventricular pressure overload: Reduction in left ventricular systolic strain predicts early mortality in pulmonary arterial hypertension. Chest. 2011;140(4). Exclude - Not a full publication.
Haroon N, Nisha RS, Chandran V, et al. Pulmonary hypertension not a major feature of early mixed connective tissue disease: a prospective clinicoserological study. J Postgrad Med. 2005;51(2):104-7. discussion 107–8. Exclude - No study population of interest. [pmid: 16006700].
Harrison RE, Berger R, Haworth SG, et al. Transforming growth factor-beta receptor mutations and pulmonary arterial hypertension in childhood. Circulation. 2005;111(4):435-41. Exclude - Does not include intervention of interest. [pmid: 15687131].
Hatano M, Yao A, Kinugawa K, et al. Acute effect of sildenafil is maintained in pulmonary arterial hypertension patients chronically treated with bosentan. Int Heart J. 2011;52(4):233-9. Exclude - no primary or secondary outcomes of interest. [pmid: 21828950].
Hatano M, Yao A, Shiga T, et al. Imatinib mesylate has the potential to exert its efficacy by down-regulating the plasma concentration of platelet-derived growth factor in patients with pulmonary arterial hypertension. Int Heart J. 2010;51(4):272-6. Exclude - Does not include intervention of interest. [pmid: 20716845].
Haworth SG, Hislop AA. Treatment and survival in children with pulmonary arterial hypertension: the UK Pulmonary Hypertension Service for Children 2001–2006. Heart. 2009;95(4):312-7. Exclude - No study population of interest. [pmid: 18952635].
He B, Zhang F, Li X, et al. Meta-analysis of randomized controlled trials on treatment of pulmonary arterial hypertension. Circ J. 2010;74(7):1458-64. Exclude - Background SR/MA. [pmid: 20519876].
Hemnes AR, Pugh ME, Newman AL, et al. End tidal CO(2) tension: pulmonary arterial hypertension vs pulmonary venous hypertension and response to treatment. Chest. 2011;140(5):1267-73. Exclude - Does not include intervention of interest. [pmid: 21622547].
Hemnes AR, Robbins IM. Sildenafil monotherapy in portopulmonary hypertension can facilitate liver transplantation. Liver Transpl. 2009;15(1):15-9. Exclude - No comparisons of interest. [pmid: 19109843].
Heper G, Polat M, Yetkin E, et al. Cardiac findings in Behcet’s patients. Int J Dermatol. 2010;49(5):574-8. Exclude - No study population of interest. [pmid: 20534096].
Heresi GA, Minai OA. Lupus-associated pulmonary hypertension: long-term response to vasoactive therapy. Respir Med. 2007;101(10):2099-107. Exclude - No comparisons of interest. [pmid: 17618103].
Hermon M, Golej J, Burda G, et al. Intravenous prostacyclin mitigates inhaled nitric oxide rebound effect: A case control study. Artif Organs. 1999;23(11):975-8. Exclude - Does not include intervention of interest. [pmid: 10564300].
Hesselstrand R, Ekman R, Eskilsson J, et al. Screening for pulmonary hypertension in systemic sclerosis: the longitudinal development of tricuspid gradient in 227 consecutive patients, 1992–2001. Rheumatology (Oxford). 2005;44(3):366-71. Exclude - no primary or secondary outcomes of interest. [pmid: 15561735].
Hesselstrand R, Wildt M, Ekmehag B, et al. Survival in patients with pulmonary arterial hypertension associated with systemic sclerosis from a Swedish single centre: prognosis still poor and prediction difficult. Scand J Rheumatol. 2011;40(2):127-32. Exclude - No comparisons of interest. [pmid: 20858146].
Higenbottam T, Butt AY, McMahon A, et al. Long-term intravenous prostaglandin (epoprostenol or iloprost) for treatment of severe pulmonary hypertension. Heart. 1998;80(2):151-5. Exclude - No comparisons of interest. [pmid: 9813561].
Higenbottam TW, Butt AY, Dinh-Xaun AT, et al. Treatment of pulmonary hypertension with the continuous infusion of a prostacyclin analogue, iloprost. Heart. 1998;79(2):175-9. Exclude - No comparisons of interest. [pmid: 9538312].
Higham MA, Dawson D, Joshi J, et al. Utility of echocardiography in assessment of pulmonary hypertension secondary to COPD. Eur Respir J. 2001;17(3):350-5. Exclude - No study population of interest. [pmid: 11405510].
Highland KB, Strange C, Mazur J, et al. Treatment of pulmonary arterial hypertension: a preliminary decision analysis. Chest. 2003;124(6):2087-92. Exclude - Does not include intervention of interest. [pmid: 14665484].
Hill KD, Lim DS, Everett AD, et al. Assessment of pulmonary hypertension in the pediatric catheterization laboratory: current insights from the Magic registry. Catheter Cardiovasc Interv. 2010;76(6):865-73. Exclude - Does not include intervention of interest. [pmid: 20549685].
Hill LL, Pearl RG. Combined inhaled nitric oxide and inhaled prostacyclin during experimental chronic pulmonary hypertension. J Appl Physiol. 1999;86(4):1160-4. Exclude - No study population of interest. [pmid: 10194197].
Hinchcliff M, Fischer A, Schiopu E, et al. Pulmonary Hypertension Assessment and Recognition of Outcomes in Scleroderma (PHAROS): baseline characteristics and description of study population. J Rheumatol. 2011;38(10):2172-9. Exclude - Background Other. [pmid: 21844142].
Hinderliter AL, Willis PWt, Long W, et al. Frequency and prognostic significance of pericardial effusion in primary pulmonary hypertension. PPH Study Group. Primary pulmonary hypertension. Am J Cardiol. 1999;84(4):481-4. A10. Exclude - No study population of interest. [pmid: 10468096].
Hinderliter AL, Willis PWt, Long WA, et al. Frequency and severity of tricuspid regurgitation determined by Doppler echocardiography in primary pulmonary hypertension. Am J Cardiol. 2003;91(8):1033-7. A9. Exclude - No comparisons of interest. [pmid: 12686360].
Hiramoto Y, Shioyama W, Kuroda T, et al. Effect of bosentan on plasma endothelin-1 concentration in patients with pulmonary arterial hypertension. Circ J. 2007;71(3):367-9. Exclude - No comparisons of interest. [pmid: 17322637].
Hirani N, Helmersen D, Brazil A, et al. First-line oral combination therapy with bosentan and sildenafil in pulmonary arterial hypertension: Preliminary results. Chest. 2011;140(4). Exclude - Not a full publication.
Hirata Y, Sata M, Makiuchi Y, et al. Comparative analysis of Micrococcus luteus isolates from blood cultures of patients with pulmonary hypertension receiving epoprostenol continuous infusion. J Infect Chemother. 2009;15(6):424-5. Exclude - No comparisons of interest. [pmid: 20012737].
Hirono K, Yoshimura N, Taguchi M, et al. Bosentan induces clinical and hemodynamic improvement in candidates for right-sided heart bypass surgery. J Thorac Cardiovasc Surg. 2010;140(2):346-51. Exclude - No study population of interest. [pmid: 20434177].
Hislop AA, Moledina S, Foster H, et al. Long-term efficacy of bosentan in treatment of pulmonary arterial hypertension in children. Eur Respir J. 2011;38(1):70-7. Exclude - No comparisons of interest. [pmid: 21177841].
Hoeper M. Is sitaxsentan a safe and efficacious treatment for pulmonary arterial hypertension?. Nat Clin Pract Cardiovasc Med. 2006;3(10):536-537. Exclude - Not a full publication. [pmid: 16990837].
Hoeper M, Barst R, Bourge R, et al. Imatinib improves exercise capacity and hemodynamics at 24 weeks as add-on therapy in symptomatic pulmonary arterial hypertension patients: The impres study. Chest. 2011;140(4). Exclude - Not a full publication.
Hoeper MM. Increasing complexities in PAH management. Br J Cardiol. 2009;16(SUPPL 1):S7-S9. Exclude - Not a full publication.
Hoeper MM, Faulenbach C, Golpon H, et al. Combination therapy with bosentan and sildenafil in idiopathic pulmonary arterial hypertension. Eur Respir J. 2004;24(6):1007-10. Exclude - No comparisons of interest. [pmid: 15572546].
Hoeper MM, Gall H, Seyfarth HJ, et al. Long-term outcome with intravenous iloprost in pulmonary arterial hypertension. Eur Respir J. 2009;34(1):132-7. Exclude - No comparisons of interest. [pmid: 19251782].
Hoeper MM, Halank M, Marx C, et al. Bosentan therapy for portopulmonary hypertension. Eur Respir J. 2005;25(3):502-8. Exclude - No comparisons of interest. [pmid: 15738295].
Hoeper MM, Markevych I, Spiekerkoetter E, et al. Goal-oriented treatment and combination therapy for pulmonary arterial hypertension. Eur Respir J. 2005;26(5):858-63. Exclude - No comparisons of interest. [pmid: 16264047].
Hoeper MM, Olschewski H, Ghofrani HA, et al. A comparison of the acute hemodynamic effects of inhaled nitric oxide and aerosolized iloprost in primary pulmonary hypertension. German PPH study group. J Am Coll Cardiol. 2000;35(1):176-82. Exclude - No comparisons of interest. [pmid: 10636277].
Hoeper MM, Schwarze M, Ehlerding S, et al. Long-term treatment of primary pulmonary hypertension with aerosolized iloprost, a prostacyclin analogue. N Engl J Med. 2000;342(25):1866-70. Exclude - No comparisons of interest. [pmid: 10861321].
Hoeper MM, Spiekerkoetter E, Westerkamp V, et al. Intravenous iloprost for treatment failure of aerosolised iloprost in pulmonary arterial hypertension. Eur Respir J. 2002;20(2):339-43. Exclude - No comparisons of interest. [pmid: 12212965].
Hoeper MM, Taha N, Bekjarova A, et al. Bosentan treatment in patients with primary pulmonary hypertension receiving nonparenteral prostanoids. Eur Respir J. 2003;22(2):330-4. Exclude - No comparisons of interest. [pmid: 12952269].
Hoeper MM, Tongers J, Leppert A, et al. Evaluation of right ventricular performance with a right ventricular ejection fraction thermodilution catheter and MRI in patients with pulmonary hypertension. Chest. 2001;120(2):502-7. Exclude - No comparisons of interest. [pmid: 11502650].
Holcomb BW, Loyd JE, Byrd BF 3rd, et al. Iatrogenic paradoxical air embolism in pulmonary hypertension. Chest. 2001;119(5):1602-5. Exclude - Does not include intervention of interest. [pmid: 11348976].
Hopkins WE, Feinberg MS, Barzilai B. Automated determination of pulmonary artery pulsatility during transesophageal echocardiography. Am J Cardiol. 1995;76(5):411-4. Exclude - No study population of interest. [pmid: 7639174].
Hopkins WE, Waggoner AD. Severe pulmonary hypertension without right ventricular failure: the unique hearts of patients with Eisenmenger syndrome. Am J Cardiol. 2002;89(1):34-8. Exclude - Does not include intervention of interest. [pmid: 11779519].
Hotchi J, Yamada H, Nishio S, et al. Efficacy of six-minute walk stress echocardiography for detection of pulmonary arterial hypertension in patients with connective tissue disease. J Am Soc Echocardiogr. 2012;25(6):B24. Exclude - Not a full publication.
Hsiao SH, Chang SM, Lee CY, et al. Usefulness of tissue Doppler parameters for identifying pulmonary embolism in patients with signs of pulmonary hypertension. Am J Cardiol. 2006;98(5):685-90. Exclude - No study population of interest. [pmid: 16923462].
Hsiao SH, Lee CY, Chang SM, et al. Right heart function in scleroderma: insights from myocardial Doppler tissue imaging. J Am Soc Echocardiogr. 2006;19(5):507-14. Exclude - no primary or secondary outcomes of interest. [pmid: 16644433].
Hsiao SH, Lee CY, Chang SM, et al. Usefulness of pulmonary arterial flow discordance to identify pulmonary embolism. Am J Cardiol. 2007;99(4):579-83. Exclude - Does not include intervention of interest. [pmid: 17293207].
Hsiao SH, Lee CY, Chang SM, et al. Pulmonary embolism and right heart function: insights from myocardial Doppler tissue imaging. J Am Soc Echocardiogr. 2006;19(6):822-8. Exclude - No study population of interest. [pmid: 16762763].
Hsiao SH, Wang WC, Yang SH, et al. Myocardial tissue Doppler-based indexes to distinguish right ventricular volume overload from right ventricular pressure overload. Am J Cardiol. 2008;101(4):536-41. Exclude - Does not include intervention of interest. [pmid: 18312773].
Hsiao SH, Yang SH, Wang WC, et al. Usefulness of regional myocardial performance index to diagnose pulmonary embolism in patients with echocardiographic signs of pulmonary hypertension. Am J Cardiol. 2006;98(12):1652-5. Exclude - No study population of interest. [pmid: 17145228].
Hsu HH, Chen JS, Chen RJ, et al. Long-term outcome and effects of oral bosentan therapy in Taiwanese patients with advanced idiopathic pulmonary arterial hypertension. Respir Med. 2007;101(7):1556-62. Exclude - No comparisons of interest. [pmid: 17223329].
Hsu HH, Chen JS, Kuo SH, et al. Effects of continuous intravenous epoprostenol therapy on advanced primary pulmonary hypertension in Taiwanese patients. J Formos Med Assoc. 2005;104(1):60-3. Exclude - No comparisons of interest. [pmid: 15660181].
Hsu V, Cheng Q, Steen V. Pulmonary hypertension assessment and recognition of outcomes in scleroderma (Pharos): Predictive factors in the development of pulmonary hypertension in a high-risk population with SSc. Rheumatology (Oxford). 2012;51:ii9-ii10. Exclude - Not a full publication.
Hsue PY, Deeks SG, Farah HH, et al. Role of HIV and human herpesvirus-8 infection in pulmonary arterial hypertension. AIDS. 2008;22(7):825-33. Exclude - No study population of interest. [pmid: 18427200].
Huez S, Brimioulle S, Naeije R, et al. Feasibility of routine pulmonary arterial impedance measurements in pulmonary hypertension. Chest. 2004;125(6):2121-8. Exclude - no primary or secondary outcomes of interest. [pmid: 15189931].
Huez S, Roufosse F, Vachiery JL, et al. Isolated right ventricular dysfunction in systemic sclerosis: latent pulmonary hypertension?. Eur Respir J. 2007;30(5):928-36. Exclude - No comparisons of interest. [pmid: 17690126].
Huez S, Vachiery JL, Unger P, et al. Tissue Doppler imaging evaluation of cardiac adaptation to severe pulmonary hypertension. Am J Cardiol. 2007;100(9):1473-8. Exclude - Does not include intervention of interest. [pmid: 17950811].
Hughes R, Tong J, Oates C, et al. Evidence for systemic endothelial dysfunction in patients and first-order relatives with pulmonary arterial hypertension. Chest. 61. 2005;128(6 Suppl):7S. Exclude - No comparisons of interest. [pmid: 16373872].
Huizinga T, Nigrovic P, Ruderman E, et al. Randomized, prospective, placebo-controlled trial of bosentan in interstitial lung disease secondary to systemic sclerosis: Commentary. International Journal of Advances in Rheumatology. 2010;8(4):146-147. Exclude - Not a full publication.
Humbert M, Sanchez O, Fartoukh M, et al. Short-term and long-term epoprostenol (prostacyclin) therapy in pulmonary hypertension secondary to connective tissue diseases: results of a pilot study. Eur Respir J. 1999;13(6):1351-6. Exclude - No comparisons of interest. [pmid: 10445611].
Humbert M, Segal ES, Kiely DG, et al. Results of European post-marketing surveillance of bosentan in pulmonary hypertension. Eur Respir J. 2007;30(2):338-44. Exclude - No comparisons of interest. [pmid: 17504794].
Hummers LK, Hall A, Wigley FM, et al. Abnormalities in the regulators of angiogenesis in patients with scleroderma. J Rheumatol. 2009;36(3):576-82. Exclude - No study population of interest. [pmid: 19228661].
Humpl T, Barst RJ, Kronmal R, et al. Current medical treatment in Pediatric Pulmonary Hypertension (PH)-Insights from the Global Registry Tracking Outcomes and Practice in Pediatric Pulmonary Hypertension (TOPP). Cardiol Young. 2012;22:S29. Exclude - Not a full publication.
Humpl T, Reyes JT, Erickson S, et al. Sildenafil therapy for neonatal and childhood pulmonary hypertensive vascular disease. Cardiol Young. 2011;21(2):187-93. Exclude - No comparisons of interest. [pmid: 21138617].
Humpl T, Reyes JT, Holtby H, et al. Beneficial effect of oral sildenafil therapy on childhood pulmonary arterial hypertension: twelve-month clinical trial of a single-drug, open-label, pilot study. Circulation. 2005;111(24):3274-80. Exclude - No comparisons of interest. [pmid: 15956137].
Hwang YI, Geun MP, Sung YK, et al. Correlation between NT-proBNP and pulmonary arterial pressure in COPD patients. Tuberc Respir Dis. 2007;63(4):346-352. Exclude - Not available in English.
Iannone F, Riccardi MT, Guiducci S, et al. Bosentan regulates the expression of adhesion molecules on circulating T cells and serum soluble adhesion molecules in systemic sclerosis-associated pulmonary arterial hypertension. Ann Rheum Dis. 2008;67(8):1121-6. Exclude - No comparisons of interest. [pmid: 18029384].
Ibrahim ES, Bajwa A. Relationship between pulmonary artery hemodynamics and right ventricle function in pulmonary arterial hypertension using cardiovascular magnetic resonance. Journal of Cardiovascular Magnetic Resonance. 2012;14. Exclude - Not a full publication.
Ibrahim R, Granton JT, Mehta S. An open-label, multicentre pilot study of bosentan in pulmonary arterial hypertension related to congenital heart disease. Can Respir J. 2006;13(8):415-20. Exclude - No comparisons of interest. [pmid: 17149459].
Ichida F, Uese K, Hamamichi Y, et al. Chronic effects of oral prostacyclin analogue on thromboxane A2 and prostacyclin metabolites in pulmonary hypertension. Acta Paediatr Jpn. 1998;40(1):14-9. Exclude - Does not include intervention of interest. [pmid: 9583194].
Ichida F, Uese K, Hashimoto I, et al. Acute effect of oral prostacyclin and inhaled nitric oxide on pulmonary hypertension in children. J Cardiol. 1997;29(4):217-24. Exclude - No study population of interest. [pmid: 9127838].
Ichida F, Uese K, Tsubata S, et al. Additive effect of beraprost on pulmonary vasodilation by inhaled nitric oxide in children with pulmonary hypertension. Am J Cardiol. 1997;80(5):662-4. Exclude - No comparisons of interest. [pmid: 9295007].
Ikeda D, Tsujino I, Ohira H, et al. Addition of oral sildenafil to beraprost is a safe and effective therapeutic option for patients with pulmonary hypertension. J Cardiovasc Pharmacol. 2005;45(4):286-9. Exclude - no primary or secondary outcomes of interest. [pmid: 15772514].
Ikeda D, Tsujino I, Sakaue S, et al. Pilot study of short-term effects of a novel long-acting oral beraprost in patients with pulmonary arterial hypertension. Circ J. 2007;71(11):1829-31. Exclude - No comparisons of interest. [pmid: 17965512].
Ilsar R, Levitt J, Adams MR, et al. Bosentan improves pulmonary microvascular endothelial function in adults with pulmonary arterial hypertension. Eur Heart J. 2009;30:110. Exclude - Not a full publication.
Ishii J. Clinical Utility of a New Marker for Cardiac Function and Heart Failure. “NT-proBNP”. Jpn J Clin Chem. 2008;37(3):283-291. Exclude - Not available in English.
Islam S, Masiakos P, Schnitzer JJ, et al. Diltiazem reduces pulmonary arterial pressures in recurrent pulmonary hypertension associated with pulmonary hypoplasia. J Pediatr Surg. 1999;34(5):712-4. Exclude - No study population of interest. [pmid: 10359169].
Ito T, Harada K, Tamura M, et al. Changes in patterns of left ventricular diastolic filling revealed by Doppler echocardiography in infants with ventricular septal defect. Cardiol Young. 1998;8(1):94-9. Exclude - No study population of interest. [pmid: 9680278].
Ittrow D, Schweikert B, Hoeper M, et al. Treatment patterns and outcomes in patients with pulmonary arterial hypertension and chronic thromboembolic pulmonary hypertension: Results of a retrospective chart review in six european countries. Value in Health. 2012;15(4):A115. Exclude - Not a full publication.
Ivy DD, Calderbank M, Wagner BD, et al. Closed-hub systems with protected connections and the reduction of risk of catheter-related bloodstream infection in pediatric patients receiving intravenous prostanoid therapy for pulmonary hypertension. Infect Control Hosp Epidemiol. 2009;30(9):823-9. Exclude - No comparisons of interest. [pmid: 19637961].
Ivy DD, Claussen L, Doran A. Transition of stable pediatric patients with pulmonary arterial hypertension from intravenous epoprostenol to intravenous treprostinil. Am J Cardiol. 2007;99(5):696-8. Exclude - No comparisons of interest. [pmid: 17317374].
Ivy DD, Doran A, Claussen L, et al. Weaning and discontinuation of epoprostenol in children with idiopathic pulmonary arterial hypertension receiving concomitant bosentan. Am J Cardiol. 2004;93(7):943-6. Exclude - No comparisons of interest. [pmid: 15050507].
Ivy DD, Doran AK, Smith KJ, et al. Short- and long-term effects of inhaled iloprost therapy in children with pulmonary arterial hypertension. J Am Coll Cardiol. 2008;51(2):161-9. Exclude - No comparisons of interest. [pmid: 18191742].
Ivy DD, Rosenzweig EB, Lemarie JC, et al. Long-term outcomes in children with pulmonary arterial hypertension treated with bosentan in real-world clinical settings. Am J Cardiol. 2010;106(9):1332-8. Exclude - No comparisons of interest. [pmid: 21029834].
Jacobs W, Boonstra A, Brand M, et al. Long-term outcomes in pulmonary arterial hypertension in the first-line epoprostenol or first-line bosentan era. J Heart Lung Transplant. 2010;29(10):1150-8. Exclude - no comparisons of interest. [pmid: 20580264].
Jais X, Launay D, Yaici A, et al. Immunosuppressive therapy in lupus- and mixed connective tissue disease-associated pulmonary arterial hypertension: a retrospective analysis of twenty-three cases. Arthritis Rheum. 2008;58(2):521-31. Exclude - No comparisons of interest. [pmid: 18240255].
Jardin F, Dubourg O, Bourdarias JP. Echocardiographic pattern of acute cor pulmonale. Chest. 1997;111(1):209-17. Exclude - Does not include intervention of interest. [pmid: 8996019].
Jensen-Urstad K, Svenungsson E, de Faire U, et al. Cardiac valvular abnormalities are frequent in systemic lupus erythematosus patients with manifest arterial disease. Lupus. 2002;11(11):744-52. Exclude - Does not include intervention of interest. [pmid: 12475005].
Jia B, Zhang S, Chen Z, et al. Plasma endothelin 1 concentrations in children with congenital heart defects. Minerva Pediatr. 1998;50(4):99-103. Exclude - No study population of interest. [pmid: 9808961].
Jiang L, Wang K, Su D, et al. Study of right ventricular contraction synchrony and function in patients with pulmonary arterial hypertension. Int J Cardiol. 2011;152:S51-S52. Exclude - Not a full publication.
Jing ZC, Jiang X, Han ZY, et al. Iloprost for pulmonary vasodilator testing in idiopathic pulmonary arterial hypertension. Eur Respir J. 2009;33(6):1354-60. Exclude - No comparisons of interest. [pmid: 19213781].
Jing ZC, Jiang X, Wu BX, et al. Vardenafil treatment for patients with pulmonary arterial hypertension: a multicentre, open-label study. Heart. 2009;95(18):1531-6. Exclude - No comparisons of interest. [pmid: 19549620].
Jing ZC, Strange G, Zhu XY, et al. Efficacy, safety and tolerability of bosentan in Chinese patients with pulmonary arterial hypertension. J Heart Lung Transplant. 2010;29(2):150-6. Exclude - No comparisons of interest. [pmid: 20113907].
Jing ZC, Xu XQ, Han ZY, et al. Registry and survival study in chinese patients with idiopathic and familial pulmonary arterial hypertension. Chest. 2007;132(2):373-9. Exclude - Does not include intervention of interest. [pmid: 17400671].
Jobard M, Vignand C, Parinaud AS, et al. Ambrisentan in pulmonary hypertension: Experience from the french reference center. Int J Clin Pharm. 2011;33(2):326-327. Exclude - Not a full publication.
Joglekar A, Tsai FS, McCloskey DA, et al. Bosentan in pulmonary arterial hypertension secondary to scleroderma. J Rheumatol. 2006;33(1):61-8. Exclude - No comparisons of interest. [pmid: 16395751].
John A, Fagondes S, Schwartz I, et al. Sleep abnormalities in untreated patients with mucopolysaccharidosis type VI. Am J Med Genet A. 2011;155A(7):1546-51. Exclude - No study population of interest. [pmid: 21638759].
Johnson MC, Kirkham FJ, Redline S, et al. Left ventricular hypertrophy and diastolic dysfunction in children with sickle cell disease are related to asleep and waking oxygen desaturation. Blood. 2010;116(1):16-21. Exclude - No study population of interest. [pmid: 20378754].
Johnson RF, Loyd JE, Mullican AL, et al. Long-term follow-up after conversion from intravenous epoprostenol to oral therapy with bosentan or sildenafil in 13 patients with pulmonary arterial hypertension. J Heart Lung Transplant. 2007;26(4):363-9. Exclude - No comparisons of interest. [pmid: 17403478].
Johnson SR, Gladman DD, Urowitz MB, et al. Pulmonary hypertension in systemic lupus. Lupus. 2004;13(7):506-9. Exclude - No comparisons of interest. [pmid: 15352421].
Jone PN, Hinzman J, Ivy D, et al. Right ventricular to left ventricular ratio in systole predicts severity of pulmonary hypertension in children. J Am Coll Cardiol. 2012;59(13):E1606. Exclude - Not a full publication.
Kadikoylu G, Onbasili A, Tekten T, et al. Functional and morphological cardiac changes in myeloproliferative disorders (clinical study). Int J Cardiol. 2004;97(2):213-20. Exclude - No study population of interest. [pmid: 15458686].
Kahler CM, Graziadei I, Wiedermann CJ, et al. Successful use of continuous intravenous prostacyclin in a patient with severe portopulmonary hypertension. Wien Klin Wochenschr. 2000;112(14):637-40. Exclude - Not a full publication. [pmid: 11008327].
Kaiser R, Lensch C, Bals R, et al. Cardiac bioimpedance for noninvasive assessment of hemodynamics in patients with pulmonary hypertension. Chest. 2011;140(4). Exclude - Not a full publication.
Kakishita M, Nishikimi T, Okano Y, et al. Increased plasma levels of adrenomedullin in patients with pulmonary hypertension. Clin Sci (Lond). 1999;96(1):33-9. Exclude - Does not include intervention of interest. [pmid: 9857104].
Kallen AJ, Lederman E, Balaji A, et al. Bloodstream infections in patients given treatment with intravenous prostanoids. Infect Control Hosp Epidemiol. 2008;29(4):342-9. Exclude - No comparisons of interest. [pmid: 18462147].
Kalogeropoulos AP, Georgiopoulou VV, Howell S, et al. Evaluation of right intraventricular dyssynchrony by two-dimensional strain echocardiography in patients with pulmonary arterial hypertension. J Am Soc Echocardiogr. 2008;21(9):1028-34. Exclude - Does not include intervention of interest. [pmid: 18558476].
Kamata S, Kamiyama M, Usui N, et al. Is adrenomedullin involved in the pathophysiology of persistent pulmonary hypertension of the newborn?. Pediatr Surg Int. 2004;20(1):24-6. Exclude - Does not include intervention of interest. [pmid: 14691636].
Kamel SR, Omar GM, Darwish AF, et al. Asymptomatic pulmonary hypertension in systemic lupus erythematosus. Clin Med Insights Arthritis Musculoskelet Disord. 2011;4:77-86. Exclude - No comparisons of interest. [pmid: 22084605].
Kampolis C, Plastiras S, Vlachoyiannopoulos P, et al. The presence of anti-centromere antibodies may predict progression of estimated pulmonary arterial systolic pressure in systemic sclerosis. Scand J Rheumatol. 2008;37(4):278-83. Exclude - no primary or secondary outcomes of interest. [pmid: 18612928].
Kaneko FT, Arroliga AC, Dweik RA, et al. Biochemical reaction products of nitric oxide as quantitative markers of primary pulmonary hypertension. Am J Respir Crit Care Med. 1998;158(3):917-23. Exclude - Does not include intervention of interest. [pmid: 9731026].
Karatza AA, Bush A, Magee AG. Safety and efficacy of Sildenafil therapy in children with pulmonary hypertension. Int J Cardiol. 2005;100(2):267-73. Exclude - No comparisons of interest. [pmid: 15823634].
Karavolias GK, Georgiadou P, Gkouziouta A, et al. Short and long term anti-inflammatory effects of bosentan therapy in patients with pulmonary arterial hypertension: relation to clinical and hemodynamic responses. Expert Opin Ther Targets. 2010;14(12):1283-9. Exclude - No comparisons of interest. [pmid: 20958219].
Karimi M, Borzouee M, Mehrabani A, et al. Echocardiographic finding in beta-thalassemia intermedia and major: absence of pulmonary hypertension following hydroxyurea treatment in beta-thalassemia intermedia. Eur J Haematol. 2009;82(3):213-8. Exclude - No study population of interest. [pmid: 19077048].
Kasparian A, Floros A, Gialafos E, et al. Raynaud’s phenomenon is correlated with elevated systolic pulmonary arterial pressure in patients with systemic lupus erythematosus. Lupus. 2007;16(7):505-8. Exclude - Does not include intervention of interest. [pmid: 17670849].
Kassem EA, Friedberg MK. Clinical significance of 2-dimensional, m-mode and doppler echo indices of rightventricular function in children with idiopathic pulmonary arterial hypertension. J Am Soc Echocardiogr. 2012;25(6):B33-B34. Exclude - Not a full publication.
Kataoka M, Satoh T, Manabe T, et al. Oral sildenafil improves primary pulmonary hypertension refractory to epoprostenol. Circ J. 2005;69(4):461-5. Exclude - No comparisons of interest. [pmid: 15791043].
Kato GJ. Risk factors for echocardiography-determined cardiopulmonary abnormalities in sickle cell anemia in the walk-PHaSST study. Blood. 2010;116(21). Exclude - Not a full publication.
Kato GJ, McGowan V, Machado RF, et al. Lactate dehydrogenase as a biomarker of hemolysis-associated nitric oxide resistance, priapism, leg ulceration, pulmonary hypertension, and death in patients with sickle cell disease. Blood. 2006;107(6):2279-85. Exclude - No study population of interest. [pmid: 16291595].
Kato GJ, Sable C, Ensing G, et al. Plasma level of NT-Pro-BNP in children with sickle cell disease is associated with degree of anemia and left ventricular measures: The PUSH study. Blood. 2010;116(21). Exclude - Not a full publication.
Katsushi H, Kazufumi N, Hideki F, et al. Epoprostenol therapy decreases elevated circulating levels of monocyte chemoattractant protein-1 in patients with primary pulmonary hypertension. Circ J. 2004;68(3):227-31. Exclude - No comparisons of interest. [pmid: 14993777].
Kavvadia V, Greenough A, Lilley J, et al. Plasma arginine levels and the response to inhaled nitric oxide in neonates. Biol Neonate. 1999;76(6):340-7. Exclude - Does not include intervention of interest. [pmid: 10567762].
Kawaguchi Y, Tochimoto A, Hara M, et al. NOS2 polymorphisms associated with the susceptibility to pulmonary arterial hypertension with systemic sclerosis: contribution to the transcriptional activity. Arthritis Res Ther. 2006;8(4):R104. Exclude - Does not include intervention of interest. [pmid: 16813666].
Kawut S. Sitaxentan in pulmonary arterial hypertension: A viewpoint by Steven Kawut. Drugs. 2007;67(5):771. Exclude - Not a full publication.
Kawut SM, Al-Naamani N, Agerstrand C, et al. Determinants of right ventricular ejection fraction in pulmonary arterial hypertension. Chest. 2009;135(3):752-9. Exclude - No comparisons of interest. [pmid: 18849396].
Kawut SM, Horn EM, Berekashvili KK, et al. von Willebrand factor independently predicts long-term survival in patients with pulmonary arterial hypertension. Chest. 2005;128(4):2355-62. Exclude - Does not include intervention of interest. [pmid: 16236894].
Kayser SR. Use of epoprostenol (Flolan) in the management of primary pulmonary hypertension. Prog Cardiovasc Nurs. 1998;13(3):39-41. 45. Exclude - Not a full publication. [pmid: 9950022].
Kayser SR. Combination drug therapy in the management of pulmonary arterial hypertension. Prog Cardiovasc Nurs. 2005;20(4):177-82. Exclude - Not a full publication. [pmid: 16276142].
Kehat R, Bonsall DJ, North R, et al. Ocular findings of oral sildenafil use in term and near-term neonates. J AAPOS. 2010;14(2):159-62. Exclude - no primary or secondary outcomes of interest. [pmid: 20199882].
Keller RL, Tacy TA, Hendricks-Munoz K, et al. Congenital diaphragmatic hernia: endothelin-1, pulmonary hypertension, and disease severity. Am J Respir Crit Care Med. 2010;182(4):555-61. Exclude - No study population of interest. [pmid: 20413632].
Kelly LK, Porta NF, Goodman DM, et al. Inhaled prostacyclin for term infants with persistent pulmonary hypertension refractory to inhaled nitric oxide. J Pediatr. 2002;141(6):830-2. Exclude - No comparisons of interest. [pmid: 12461501].
Keogh A, Strange G, McNeil K, et al. The bosentan patient registry: long-term survival in pulmonary arterial hypertension. Intern Med J. 2011;41(3):227-34. Exclude - No comparisons of interest. [pmid: 20002851].
Keogh AM, Jabbour A, Hayward CS, et al. Clinical deterioration after sildenafil cessation in patients with pulmonary hypertension. Vasc Health Risk Manag. 2008;4(5):1111-3. Exclude - No comparisons of interest. [pmid: 19183760].
Keogh AM, Jabbour A, Weintraub R, et al. Safety and efficacy of transition from subcutaneous treprostinil to oral sildenafil in patients with pulmonary arterial hypertension. J Heart Lung Transplant. 2007;26(11):1079-83. Exclude - No comparisons of interest. [pmid: 18022071].
Keogh AM, McNeil KD, Wlodarczyk J, et al. Quality of life in pulmonary arterial hypertension: improvement and maintenance with bosentan. J Heart Lung Transplant. 2007;26(2):181-7. Exclude - No comparisons of interest. [pmid: 17258153].
Kereveur A, Callebert J, Humbert M, et al. High plasma serotonin levels in primary pulmonary hypertension. Effect of long-term epoprostenol (prostacyclin) therapy. Arterioscler Thromb Vasc Biol. 2000;20(10):2233-9. Exclude - No comparisons of interest. [pmid: 11031209].
Kermeen FD, Franks C, O’Brien K, et al. Endothelin receptor antagonists are an effective long term treatment option in pulmonary arterial hypertension associated with congenital heart disease with or without trisomy 21. Heart Lung Circ. 2010;19(10):595-600. Exclude - No comparisons of interest. [pmid: 20728407].
Keser G, Capar I, Aksu K, et al. Pulmonary hypertension in rheumatoid arthritis. Scand J Rheumatol. 2004;33(4):244-5. Exclude - No comparisons of interest. [pmid: 15370720].
Kharitonov SA, Cailes JB, Black CM, et al. Decreased nitric oxide in the exhaled air of patients with systemic sclerosis with pulmonary hypertension. Thorax. 1997;52(12):1051-5. Exclude - No comparisons of interest. [pmid: 9516898].
Khorana M, Yookaseam T, Layangool T, et al. Outcome of oral sildenafil therapy on persistent pulmonary hypertension of the newborn at Queen Sirikit National Institute of Child Health. J Med Assoc Thai. Suppl 3. 2011;94:S64-73. Exclude - No comparisons of interest. [pmid: 22043756].
Kiatchoosakun S, Ungkasekvinai W, Wonvipaporn C, et al. D-dimer and pulmonary arterial hypertension in systemic sclerosis. J Med Assoc Thai. 2007;90(10):2024-9. Exclude - No comparisons of interest. [pmid: 18041419].
Kiatchoosakun S, Wongvipaporn C, Nanagara R, et al. Right ventricular systolic pressure assessed by echocardiography: a predictive factor of mortality in patients with scleroderma. Clin Cardiol. 2011;34(8):488-93. Exclude - No comparisons of interest. [pmid: 21717471].
Kielstein JT, Bode-Boger SM, Hesse G, et al. Asymmetrical dimethylarginine in idiopathic pulmonary arterial hypertension. Arterioscler Thromb Vasc Biol. 2005;25(7):1414-8. Exclude - No comparisons of interest. [pmid: 15860741].
Kiettisanpipop P, Lertsapcharorn P, Chotivittayatarakorn P, et al. Plasma levels of nitric oxide in children with congenital heart disease and increased pulmonary blood flow. J Med Assoc Thai. 2007;90(10):2053-7. Exclude - No comparisons of interest. [pmid: 18041423].
Kim HW, Kim GB, Je HG, et al. Pulmonary arterial hypertension in children: A single center experience. Korean Circ J. 2008;38(12):644-650. Exclude - No comparisons of interest.
Kim KJ, Kim JY, Park SJ, et al. Prevalence and associated factors for asymptomatic pulmonary arterial hypertension in patients with systemic lupus erythematosus. Arthritis Rheum. 2011;63(10). Exclude - Not a full publication.
Kim KJ, Yoon HS, Yoon CH, et al. Prevalence and associated factors for asymptomatic pulmonary arterial hypertension in patients with systemic lupus erythematosus. Inflamm Res. 2011;60:S217-S218. Exclude - Not a full publication.
Kim LH, Korn JH. Update in systemic sclerosis. Arthritis Care Res. 2003;49(4):605-613. Exclude - Background Other.
Kim MA, Kim DK, Lee CH, et al. The correlation of brain natriuretic peptide (BNP), pulmonary arterial pressure, and St. George Respiratory Questionnaire (SGRQ) and their changes with a trial of an angiotensin converting enzyme inhibitor. Tuberc Respir Dis. 2010;68(5):273-279. Exclude - Not available in English.
Kim WH, Otsuji Y, Seward JB, et al. Estimation of left ventricular function in right ventricular volume and pressure overload. Detection of early left ventricular dysfunction by Tei index. Jpn Heart J. 1999;40(2):145-54. Exclude - no primary or secondary outcomes of interest. [pmid: 10420876].
Kim WR, Krowka MJ, Plevak DJ, et al. Accuracy of Doppler echocardiography in the assessment of pulmonary hypertension in liver transplant candidates. Liver Transpl. 2000;6(4):453-8. Exclude - No comparisons of interest. [pmid: 10915168].
Kincaid L. Promise in the PAH pipeline. Good Clin Pract J. 2006;13(5):26-27. Exclude - Not a full publication.
King P, Tulloh R. Management of pulmonary hypertension and Down syndrome. Int J Clin Pract. 2011;65(SUPPL 174):8-13. Exclude - Background Other.
Kingman MS, Tankersley MA, Lombardi S, et al. Prostacyclin administration errors in pulmonary arterial hypertension patients admitted to hospitals in the United States: a national survey. J Heart Lung Transplant. 2010;29(8):841-6. Exclude - No comparisons of interest. [pmid: 20430649].
Kittipovanonth M, Bellavia D, Chandrasekaran K, et al. Doppler myocardial imaging for early detection of right ventricular dysfunction in patients with pulmonary hypertension. J Am Soc Echocardiogr. 2008;21(9):1035-41. Exclude - Does not include intervention of interest. [pmid: 18765178].
Klinger JR, Oudiz RJ, Spence R, et al. Long-term pulmonary hemodynamic effects of ambrisentan in pulmonary arterial hypertension. Am J Cardiol. 2011;108(2):302-7. Exclude - No comparisons of interest. [pmid: 21545989].
Klinger JR, Thaker S, Houtchens J, et al. Pulmonary hemodynamic responses to brain natriuretic peptide and sildenafil in patients with pulmonary arterial hypertension. Chest. 2006;129(2):417-25. Exclude - no primary or secondary outcomes of interest. [pmid: 16478861].
Klings ES, Anton Bland D, Rosenman D, et al. Pulmonary arterial hypertension and left-sided heart disease in sickle cell disease: clinical characteristics and association with soluble adhesion molecule expression. Am J Hematol. 2008;83(7):547-53. Exclude - No comparisons of interest. [pmid: 18383329].
Klings ES, Hill NS, Ieong MH, et al. Systemic sclerosis-associated pulmonary hypertension: short- and long-term effects of epoprostenol (prostacyclin). Arthritis Rheum. 1999;42(12):2638-45. Exclude - No comparisons of interest. [pmid: 10616012].
Knight-Perry JE, de Las Fuentes L, Waggoner AD, et al. Abnormalities in cardiac structure and function in adults with sickle cell disease are not associated with pulmonary hypertension. J Am Soc Echocardiogr. 2011;24(11):1285-90. Exclude - no primary or secondary outcomes of interest. [pmid: 21873028].
Knirsch W, Hausermann E, Fasnacht M, et al. Effect of medical treatment on plasma B-type natriuretic peptide levels and 6 min walking test in children with pulmonary hypertension. Clin Res Cardiol. 2011;100(9):858-859. Exclude - Not a full publication.
Knudsen L, Schurawlew A, Nickel N, et al. Long-term effects of intravenous iloprost in patients with idiopathic pulmonary arterial hypertension deteriorating on non-parenteral therapy. BMC Pulm Med. 2011;11(1):56. Exclude - No comparisons of interest. [pmid: 22133492].
Koca F, Tanboga IH, Can MM, et al. Neutrophil gelatinase-associated lipocalin levels in right and left heart failure: An observational study. Anadolu Kardiyol Derg. 2011;11(6):498-503. Exclude - no primary or secondary outcomes of interest. [pmid: 21788201].
Kojonazarov BK, Imanov BZ, Amatov TA, et al. Noninvasive and invasive evaluation of pulmonary arterial pressure in highlanders. Eur Respir J. 2007;29(2):352-6. Exclude - No study population of interest. [pmid: 17079253].
Kong D, Shu X, Pan C, et al. Evaluation of right ventricular regional volume and systolic function in patients with pulmonary arterial hypertension using three-dimensional echocardiography. J Am Soc Echocardiogr. 2012;25(6):B74-B75. Exclude - Not a full publication.
Kong D, Shu X, Pan C, et al. Rightventricular regional systolic function and dyssynchrony in patients with pulmonary hypertension evaluated by three-dimensional echocardiography. J Am Soc Echocardiogr. 2012;25(6):B106. Exclude - Not a full publication.
Kong KO, Badsha H, Thumboo J, et al. Intermittent epoprostenol infusions in systemic lupus erythematosus associated pulmonary hypertension--a series of three cases. Ann Acad Med Singapore. 2003;32(1):118-21. Exclude - No comparisons of interest. [pmid: 12625109].
Kotake F, Kobayashi J, Sonoda M, et al. Nitric oxide-related compounds in patients with congenital heart defects and pulmonary hypertension. Pediatr Int. 2000;42(3):249-54. Exclude - No comparisons of interest. [pmid: 10881580].
Kothari SS, Duggal B. Chronic oral sildenafil therapy in severe pulmonary artery hypertension. Indian Heart J. 2002;54(4):404-9. Exclude - No comparisons of interest. [pmid: 12462669].
Kotlyar E, Sy R, Keogh AM, et al. Bosentan for the treatment of pulmonary arterial hypertension associated with congenital cardiac disease. Cardiol Young. 2006;16(3):268-74. Exclude - No comparisons of interest. [pmid: 16725066].
Kourouklis S, Christopoulos A, Liagkas K, et al. Bosentan in Eisenmenger syndrome and chronic thromboembolic pulmonary hypertension. Eur J Clin Invest. Suppl 3. 2006;36:39-43. Exclude - Not a full publication. [pmid: 16919009].
Kouzu H, Nakatani S, Kyotani S, et al. Noninvasive estimation of pulmonary vascular resistance by Doppler echocardiography in patients with pulmonary arterial hypertension. Am J Cardiol. 2009;103(6):872-6. Exclude - No comparisons of interest. [pmid: 19268748].
Kovacs G, Kqiku X, Maier R, et al. Early therapy with bosentan may reverse pulmonary vasculopathy in scleroderma patients. Pneumologie. 2010;64. Exclude - Not a full publication.
Kovacs G, Maier R, Aberer E, et al. Pulmonary arterial hypertension therapy may be safe and effective in patients with systemic sclerosis and borderline pulmonary pressures. Arthritis Rheum. 2011. Exclude - No comparisons of interest. [pmid: 22127844].
Kowal-Bielecka O, Avouac J, Pittrow D, et al. Analysis of the validation status of Quality of Life and Functional Disability Measures in Pulmonary Arterial Hypertension related to systemic sclerosis: results of a systematic literature Analysis by the Expert Panel on Outcomes Measures in Pulmonary Arterial Hypertension related to systemic sclerosis (EPOSS). J Rheumatol. 2011;38(11):2419-27. Exclude - Not a full publication. [pmid: 21965635].
Krasuski RA, Warner JJ, Wang A, et al. Inhaled nitric oxide selectively dilates pulmonary vasculature in adult patients with pulmonary hypertension, irrespective of etiology. J Am Coll Cardiol. 2000;36(7):2204-11. Exclude - no primary or secondary outcomes of interest. [pmid: 11127462].
Krowka MJ, Frantz RP, McGoon MD, et al. Improvement in pulmonary hemodynamics during intravenous epoprostenol (prostacyclin): A study of 15 patients with moderate to severe portopulmonary hypertension. Hepatology. 1999;30(3):641-8. Exclude - No comparisons of interest. [pmid: 10462369].
Krowka MJ, Swanson KL, Frantz RP, et al. Portopulmonary hypertension: Results from a 10-year screening algorithm. Hepatology. 2006;44(6):1502-10. Exclude - No comparisons of interest. [pmid: 17133488].
Kubanek M, Malek I, Kautzner J, et al. The value of B-type natriuretic peptide and big endothelin-1 for detection of severe pulmonary hypertension in heart transplant candidates. Eur J Heart Fail. 2005;7(7):1149-55. Exclude - No comparisons of interest. [pmid: 15916922].
Kuhn KP, Byrne DW, Arbogast PG, et al. Outcome in 91 consecutive patients with pulmonary arterial hypertension receiving epoprostenol. Am J Respir Crit Care Med. 2003;167(4):580-6. Exclude - No comparisons of interest. [pmid: 12446266].
Kuhn KP, Wickersham NE, Robbins IM, et al. Acute effects of sildenafil in patients with primary pulmonary hypertension receiving epoprostenol. Exp Lung Res. 2004;30(2):135-45. Exclude - no primary or secondary outcomes of interest. [pmid: 14972773].
Kulkarni A. Changing trends in neonatal pharmacotherapy. Perinatology. 2004;6(5):231-236. Exclude - Not a full publication.
Kulkarni H, Srinivas A, Vora A, et al. Acute hemodynamic response to vasodilators in primary pulmonary hypertension. J Postgrad Med. 1996;42(1):7-11. Exclude - no primary or secondary outcomes of interest. [pmid: 9715289].
Kumar P, Kazzi NJ, Shankaran S. Plasma immunoreactive endothelin-1 concentrations in infants with persistent pulmonary hypertension of the newborn. Am J Perinatol. 1996;13(6):335-41. Exclude - No study population of interest. [pmid: 8865978].
Kumar U, Gokhle SS, Sreenivas V, et al. Prospective, open-label, uncontrolled pilot study to study safety and efficacy of sildenafil in systemic sclerosis-related pulmonary artery hypertension and cutaneous vascular complications. Rheumatol Int. 2012:1-6. Exclude - No study population of interest.
Kumar U, Ramteke R, Yadav R, et al. Prevalence and predictors of pulmonary artery hypertension in systemic sclerosis. J Assoc Physicians India. 2008;56:413-7. Exclude - No comparisons of interest. [pmid: 18822619].
Kumbhani DJ, Bhatt DL. Ambrisentan in pulmonary arterial hypertension efficacy study 1 and 2 (Aries 1 and 2). ACC Cardiosource Rev J. 2008;17(7):41. Exclude - Not a full publication.
Kumpers P, Nickel N, Lukasz A, et al. Circulating angiopoietins in idiopathic pulmonary arterial hypertension. Eur Heart J. 2010;31(18):2291-300. Exclude - No comparisons of interest. [pmid: 20601390].
Kunieda T, Nakanishi N, Matsubara H, et al. Effects of long-acting beraprost sodium (TRK-100STP) in Japanese patients with pulmonary arterial hypertension. Int Heart J. 2009;50(4):513-29. Exclude - Does not include intervention of interest. [pmid: 19609055].
Kuntzen C, Gulberg V, Gerbes AL. Use of a mixed endothelin receptor antagonist in portopulmonary hypertension: a safe and effective therapy?. Gastroenterology. 2005;128(1):164-8. Exclude - Not a full publication. [pmid: 15633133].
Kuo PC, Alfrey EJ, Li K, et al. Magnetic resonance imaging-derived parameter of portal flow predicts volume-mediated pulmonary hypertension in liver transplantation candidates. Surgery. 1995;118(4):685-91. discussion 691–2. Exclude - Does not include intervention of interest. [pmid: 7570323].
Kuo PC, Plotkin JS, Johnson LB, et al. Distinctive clinical features of portopulmonary hypertension. Chest. 1997;112(4):980-6. Exclude - No comparisons of interest. [pmid: 9377962].
Kuo PC, Schroeder RA, Vagelos RH, et al. Volume-mediated pulmonary responses in liver transplant candidates. Clin Transplant. 1996;10(6 Pt 1):521-7. Exclude - Does not include intervention of interest. [pmid: 8996773].
Kupecz D, Berardinelli C. Ease symptoms of pulmonary hypertension with bosentan. Nurse Pract. 2002;27(6):51-3. Exclude - Not a full publication. [pmid: 12094086].
Kurzyna M, Zylkowska J, Fijalkowska A, et al. Characteristics and prognosis of patients with decompensated right ventricular failure during the course of pulmonary hypertension. Kardiol Pol. 2008;66(10):1033-9. discussion 1040–1. Exclude - Does not include intervention of interest. [pmid: 19006024].
Kylhammar D, Kornhall B, Persson L, et al. Haemodynamic effects of first-line single- or combination therapy in patients with idiopathic or familial pulmonary arterial hypertension from the Lund cohort of the Swedish Pulmonary Arterial Hypertension Registry. Scand Cardiovasc J. 2012;46:15. Exclude - Not a full publication.
Kyriazis J, Papagiannis N, Kavouria E, et al. The role of tissue doppler imaging (TDI) in the evaluation of pulmonary hypertension (PH) in hemodialysis (HD) patients. NDT Plus. 2010;3:iii178. Exclude - Not a full publication.
Lakshmanan RV, Sharma A, Khanduja K, et al. Preoperative transthoracic echocardiography does not predict intraoperative systolic pulmonary artery pressure in liver transplant candidates. Liver Transplantation. 2012;18:S127. Exclude - Not a full publication.
Lal MK, Field DJ. Clinical management of persistent pulmonary hypertension of the newborn. Perinatology. 2001;3(5):249-261. Exclude - unable to obtain full-text.
Lammers AE, Hislop AA, Flynn Y, et al. Epoprostenol treatment in children with severe pulmonary hypertension. Heart. 2007;93(6):739-43. Exclude - No comparisons of interest. [pmid: 17065181].
Landburg PP, Teerlink T, Biemond BJ, et al. Plasma asymmetric dimethylarginine concentrations in sickle cell disease are related to the hemolytic phenotype. Blood Cells Mol Dis. 2010;44(4):229-32. Exclude - no primary or secondary outcomes of interest. [pmid: 20185345].
Lang I, Gomez-Sanchez M, Kneussl M, et al. Efficacy of long-term subcutaneous treprostinil sodium therapy in pulmonary hypertension. Chest. 2006;129(6):1636-43. Exclude - No comparisons of interest. [pmid: 16778286].
Langer F, Wilhelm W, Tscholl D, et al. Intraoperative inhalation of the long-acting prostacyclin analog iloprost for pulmonary hypertension. J Thorac Cardiovasc Surg. 2003;126(3):874-5. Exclude - No study population of interest. [pmid: 14502175].
Langleben D, Brock T, Dixon R, et al. STRIDE 1: effects of the selective ET(A) receptor antagonist, sitaxsentan sodium, in a patient population with pulmonary arterial hypertension that meets traditional inclusion criteria of previous pulmonary arterial hypertension trials. J Cardiovasc Pharmacol. Suppl 1. 2004;44:S80-4. Exclude - Does not include intervention of interest. [pmid: 15838366].
Langleben D, Cacoub P. A review of STRIDE-2 and STRIDE-2X: the case for selective endothelin receptor blockade. Eur J Clin Invest. Suppl 2. 2009;39:27-31. Exclude - Not a full publication. [pmid: 19335744].
Langleben D, Hirsch AM, Shalit E, et al. Sustained symptomatic, functional, and hemodynamic benefit with the selective endothelin-A receptor antagonist, sitaxsentan, in patients with pulmonary arterial hypertension: a 1-year follow-up study. Chest. 2004;126(4):1377-81. Exclude - Does not include intervention of interest. [pmid: 15486408].
Lanzarini L, Fontana A, Campana C, et al. Two simple echo-Doppler measurements can accurately identify pulmonary hypertension in the large majority of patients with chronic heart failure. J Heart Lung Transplant. 2005;24(6):745-54. Exclude - No study population of interest. [pmid: 15949736].
Lapa M, Dias B, Jardim C, et al. Cardiopulmonary manifestations of hepatosplenic schistosomiasis. Circulation. 2009;119(11):1518-23. Exclude - Does not include intervention of interest. [pmid: 19273723].
Larsen KO, Yndestad A, Sjaastad I, et al. Lack of CCR7 induces pulmonary hypertension involving perivascular leukocyte infiltration and inflammation. Am J Physiol Lung Cell Mol Physiol. 2011;301(1):L50-9. Exclude - Not a full publication. [pmid: 21498626].
Launay D. Pulmonary hypertension, the “bete noire” of systemic diseases: from systemic sclerosis to hereditary hemorrhagic telangiectasia. Rev Med Interne. 2006;27(11):899-902. Exclude - Not available in English. [pmid: 17133666].
Launay D, Hachulla E, Hatron PY, et al. Aerosolized iloprost in CREST syndrome related pulmonary hypertension. J Rheumatol. 2001;28(10):2252-6. Exclude - No comparisons of interest. [pmid: 11669165].
Launay D, Hachulla E, Hatron PY, et al. Pulmonary arterial hypertension: a rare complication of primary Sjogren syndrome: report of 9 new cases and review of the literature. Medicine (Baltimore). 2007;86(5):299-315. Exclude - Not a full publication. [pmid: 17873760].
Launay D, Mouthon L, Hachulla E, et al. Prevalence and characteristics of moderate to severe pulmonary hypertension in systemic sclerosis with and without interstitial lung disease. J Rheumatol. 2007;34(5):1005-11. Exclude - No comparisons of interest. [pmid: 17444586].
Launay D, Sitbon O, Cordier JF, et al. Survival and prognostic factors in patients with incident systemic sclerosis-associated pulmonary arterial hypertension from the French registry. Eur Heart J. 2011;32:174. Exclude - Not a full publication.
Launay D, Sitbon O, Le Pavec J, et al. Long-term outcome of systemic sclerosis-associated pulmonary arterial hypertension treated with bosentan as first-line monotherapy followed or not by the addition of prostanoids or sildenafil. Rheumatology (Oxford). 2010;49(3):490-500. Exclude - no comparisons of interest. [pmid: 20015974].
Lawrie A, Waterman E, Southwood M, et al. Evidence of a role for osteoprotegerin in the pathogenesis of pulmonary arterial hypertension. Am J Pathol. 2008;172(1):256-64. Exclude - No comparisons of interest. [pmid: 18156213].
Le Ven F, Tribouilloy C, Habib G, et al. Valvular heart disease associated with benfluorex therapy: results from the French multicentre registry. Eur J Echocardiogr. 2011;12(4):265-71. Exclude - No comparisons of interest. [pmid: 21193484].
Leal GN, de Paula AC, Leone C, et al. Echocardiographic study of paediatric patients with mucopolysaccharidosis. Cardiol Young. 2010;20(3):254-61. Exclude - Does not include intervention of interest. [pmid: 20416133].
Lee AJ, Chiao TB, Tsang MP. Sildenafil for pulmonary hypertention. Ann Pharmacother. 2005;39(5):869-884. Exclude - Background SR/MA. [pmid: 15827074].
Lee H, Kim SY, Lee SJ, et al. Potential of right to left ventricular volume ratio measured on chest CT for the prediction of pulmonary hypertension: correlation with pulmonary arterial systolic pressure estimated by echocardiography. Eur Radiol. 2012:1-8. Exclude - Does not include intervention of interest.
Lee MT, Small T, Khan MA, et al. Doppler-defined pulmonary hypertension and the risk of death in children with sickle cell disease followed for a mean of three years. Br J Haematol. 2009;146(4):437-41. Exclude - no primary or secondary outcomes of interest. [pmid: 19563512].
Lee S, Chung W. Interplay between body mass index and brain natriuretic peptide in screening for pulmonary arterial hypertension in SSc. Rheumatology (Oxford). 2012;51:ii81. Exclude - Not a full publication.
Lei MH, Chen JJ, Ko YL, et al. Reappraisal of quantitative evaluation of pulmonary regurgitation and estimation of pulmonary artery pressure by continuous wave Doppler echocardiography. Cardiology. 1995;86(3):249-56. Exclude - No comparisons of interest. [pmid: 7614499].
Lepore JJ, Maroo A, Pereira NL, et al. Effect of sildenafil on the acute pulmonary vasodilator response to inhaled nitric oxide in adults with primary pulmonary hypertension. Am J Cardiol. 2002;90(6):677-80. Exclude - no primary or secondary outcomes of interest. [pmid: 12231108].
Leuchte HH, El Nounou M, Tuerpe JC, et al. N-terminal pro-brain natriuretic peptide and renal insufficiency as predictors of mortality in pulmonary hypertension. Chest. 2007;131(2):402-9. Exclude - No comparisons of interest. [pmid: 17296640].
Leuchte HH, Schwaiblmair M, Baumgartner RA, et al. Hemodynamic response to sildenafil, nitric oxide, and iloprost in primary pulmonary hypertension. Chest. 2004;125(2):580-6. Exclude - no primary or secondary outcomes of interest. [pmid: 14769741].
Ley S, Mereles D, Puderbach M, et al. Value of MR phase-contrast flow measurements for functional assessment of pulmonary arterial hypertension. Eur Radiol. 2007;17(7):1892-7. Exclude - Does not include intervention of interest. [pmid: 17225131].
Li EK, Tam LS. Pulmonary hypertension in systemic lupus erythematosus: clinical association and survival in 18 patients. J Rheumatol. 1999;26(9):1923-9. Exclude - Does not include intervention of interest. [pmid: 10493670].
Li YD, Wu YF, Ma ZH, et al. Correlation of hemodynamic parameters measured with echocardiography and those obtained with right heart catheterization in patients of pulmonary hypertension. Chinese Journal of Medical Imaging Technology. 2011;27(7):1405-1408. Exclude - Not a full publication.
Liem RI, Nevin MA, Prestridge A, et al. Tricuspid regurgitant jet velocity elevation and its relationship to lung function in pediatric sickle cell disease. Pediatr Pulmonol. 2009;44(3):281-9. Exclude - Does not include intervention of interest. [pmid: 19205056].
Liem RI, Young LT, Lay AS, et al. Reproducibility of tricuspid regurgitant jet velocity measurements in children and young adults with sickle cell disease undergoing screening for pulmonary hypertension. Am J Hematol. 2010;85(10):741-5. Exclude - Does not include intervention of interest. [pmid: 20652966].
Limsuwan A, Khosithseth A, Wanichkul S, et al. Aerosolized iloprost for pulmonary vasoreactivity testing in children with long-standing pulmonary hypertension related to congenital heart disease. Catheter Cardiovasc Interv. 2009;73(1):98-104. Exclude - No comparisons of interest. [pmid: 19089967].
Limsuwan A, Wanitkul S, Khosithset A, et al. Aerosolized iloprost for postoperative pulmonary hypertensive crisis in children with congenital heart disease. Int J Cardiol. 2008;129(3):333-8. Exclude - No comparisons of interest. [pmid: 18096256].
Lin SC, Chen RJC, Lee JH. The correlation between right descending pulmonary artery diameter and echocardiography-estimated systolic pulmonary artery pressure. Acta Cardiol Sin. 2009;25(4):213-217. Exclude - Does not include intervention of interest.
Lise MC, Sparsa A, Marie I, et al. Serum neurotrophin profile in systemic sclerosis. PLoS One. 2010;5(11). Exclude - no primary or secondary outcomes of interest.
Liu J, Feng ZC. Changes in pulmonary arterial pressure in term-infants with hypoxic-ischemic encephalopathy. Pediatr Int. 2009;51(6):786-9. Exclude - No study population of interest. [pmid: 19419507].
Liu YT, Li MT, Fang Q, et al. Right-heart function related to the results of acute pulmonary vasodilator testing in patients with pulmonary arterial hypertension caused by connective tissue disease. J Am Soc Echocardiogr. 2012;25(3):274-9. Exclude - no primary or secondary outcomes of interest. [pmid: 22137255].
Liu YT, Li MT, Tian Z, et al. Right-Heart Function Related to the Results of Acute Pulmonary Vasodilator Testing in Patients with Pulmonary Arterial Hypertension Caused by Connective Tissue Disease. J Am Soc Echocardiogr. 2011. Exclude - Does not include intervention of interest. [pmid: 22137255].
LoBuono C. Pulmonary hypertension guidelines include latest drugs. Drug Topics. 2004;148(16):29. Exclude - Not a full publication Exclude - Not a full publication.
LoBuono C. First inhaled prostacyclin for pulmonary hypertension. Drug Topics. 2005;149(4). Exclude - Not a full publication.
Lopes AA, Barreto AC, Maeda NY, et al. Plasma von Willebrand factor as a predictor of survival in pulmonary arterial hypertension associated with congenital heart disease. Braz J Med Biol Res. 2011;44(12):1269-1275. Exclude - Does not include intervention of interest. [pmid: 22068906].
Lopes AA, Maeda NY, Bydlowski SP. Abnormalities in circulating von Willebrand factor and survival in pulmonary hypertension. Am J Med. 1998;105(1):21-6. Exclude - Does not include intervention of interest. [pmid: 9688017].
Lopes AA, Maeda NY, Goncalves RC, et al. Endothelial cell dysfunction correlates differentially with survival in primary and secondary pulmonary hypertension. Am Heart J. 2000;139(4):618-23. Exclude - Does not include intervention of interest. [pmid: 10740142].
Lopes LR, Loureiro MJ, Miranda R, et al. The usefulness of contrast during exercise echocardiography for the assessment of systolic pulmonary pressure. Cardiovasc Ultrasound. 2008;6:51. Exclude - Does not include intervention of interest. [pmid: 18851729].
Lopez-Candales A, Bazaz R, Edelman K, et al. Apical systolic eccentricity index: a better marker of right ventricular compromise in pulmonary hypertension. Echocardiography. 2010;27(5):534-8. Exclude - no primary or secondary outcomes of interest. [pmid: 20345450].
Lopez-Candales A, Dohi K, Bazaz R, et al. Relation of right ventricular free wall mechanical delay to right ventricular dysfunction as determined by tissue Doppler imaging. Am J Cardiol. 2005;96(4):602-6. Exclude - no primary or secondary outcomes of interest. [pmid: 16098321].
Lopez-Candales A, Dohi K, Iliescu A, et al. An abnormal right ventricular apical angle is indicative of global right ventricular impairment. Echocardiography. 2006;23(5):361-8. Exclude - no primary or secondary outcomes of interest. [pmid: 16686617].
Lopez-Candales A, Dohi K, Rajagopalan N, et al. Defining normal variables of right ventricular size and function in pulmonary hypertension: an echocardiographic study. Postgrad Med J. 2008;84(987):40-5. Exclude - Does not include intervention of interest. [pmid: 18230750].
Lopez-Candales A, Dohi K, Rajagopalan N, et al. Right ventricular dyssynchrony in patients with pulmonary hypertension is associated with disease severity and functional class. Cardiovasc Ultrasound. 2005;3:23. Exclude - Does not include intervention of interest. [pmid: 16129028].
Lopez-Candales A, Edelman K. Ratio of right to left ventricular ejection: a pilot study using Doppler to detect interventricular dyssynchrony. Clin Cardiol. 2011;34(6):366-71. Exclude - no primary or secondary outcomes of interest. [pmid: 21538384].
Lopez-Candales A, Edelman K, Gulyasy B. The effect of chronic pulmonary hypertension on diastolic annular tissue velocities: a pilot study. Am J Med Sci. 2011;341(5):344-9. Exclude - no primary or secondary outcomes of interest. [pmid: 21478731].
Lopez-Candales A, Edelman K, Gulyasy B, et al. New annular tissue Doppler markers of pulmonary hypertension. Echocardiography. 2010;27(8):969-76. Exclude - no primary or secondary outcomes of interest. [pmid: 20849485].
Lopez-Candales A, Eleswarapu A, Shaver J, et al. Right ventricular outflow tract spectral signal: a useful marker of right ventricular systolic performance and pulmonary hypertension severity. Eur J Echocardiogr. 2010;11(6):509-15. Exclude - no primary or secondary outcomes of interest. [pmid: 20207723].
Lopez-Candales A, Rajagopalan N, Dohi K, et al. Normal range of mechanical variables in pulmonary hypertension: a tissue Doppler imaging study. Echocardiography. 2008;25(8):864-72. Exclude - no primary or secondary outcomes of interest. [pmid: 18986414].
Lopez-Candales A, Rajagopalan N, Dohi K, et al. Abnormal right ventricular myocardial strain generation in mild pulmonary hypertension. Echocardiography. 2007;24(6):615-22. Exclude - No comparisons of interest. [pmid: 17584201].
Lopez-Candales A, Rajagopalan N, Gulyasy B, et al. A delayed time of the peak tricuspid regurgitation signal: marker of right ventricular dysfunction. Am J Med Sci. 2008;336(3):224-9. Exclude - no primary or secondary outcomes of interest. [pmid: 18794616].
Lopez-Candales A, Rajagopalan N, Gulyasy B, et al. Differential strain and velocity generation along the right ventricular free wall in pulmonary hypertension. Can J Cardiol. 2009;25(3):e73-7. Exclude - no primary or secondary outcomes of interest. [pmid: 19279990].
Lopez-Medrano F, Fernandez-Ruiz M, Ruiz-Cano MJ, et al. High Incidence of Bloodstream Infection Due to Gram-negative Bacilli in Patients With Pulmonary Hypertension Receiving Intravenous Treprostinil. Arch Bronconeumol. 2012. Exclude - Not a full publication.
Loukanov T, Arnold R, Gross J, et al. Endothelin-1 and asymmetric dimethylarginine in children with left-to-right shunt after intracardiac repair. Clin Res Cardiol. 2008;97(6):383-8. Exclude - no primary or secondary outcomes of interest. [pmid: 18297323].
Low A, Teng GG, Law WG, et al. Association of pulmonary hypertension by echocardiography with clinical parameters in Asian patients with SSc. Rheumatology (Oxford). 2012;51:ii80-ii81. Exclude - Not a full publication.
Low AHL, Tan YS, Yoong J, et al. Relationship between quantitative nail-fold capillaroscopic measurements and echocardiographic pulmonary arterial systolic pressure in SSc. Rheumatology (Oxford). 2012;51:ii80. Exclude - Not a full publication.
Lu H, Chen S, Wang H, et al. Role of adrenomedullin in congenital heart disease associated with pulmonary hypertension. J Huazhong Univ Sci Technolog Med Sci. 2003;23(3):275-7. Exclude - No study population of interest. [pmid: 14526432].
Lu XL, Xiong CM, Shan GL, et al. Impact of sildenafil therapy on pulmonary arterial hypertension in adults with congenital heart disease. Cardiovasc Ther. 2010;28(6):350-5. Exclude - No comparisons of interest. [pmid: 20637015].
Lunardini A, Spadoni I, De Lucia V, et al. Advanced therapies in adult and pediatric patients with pulmonary arterial hypertension associated with congenital heart disease: Mid-term follow-up results. G Ital Cardiol. 2011;12(10):37S. Exclude - Not a full publication.
Lunze K, Gilbert N, Mebus S, et al. First experience with an oral combination therapy using bosentan and sildenafil for pulmonary arterial hypertension. Eur J Clin Invest. Suppl 3. 2006;36:32-8. Exclude - No comparisons of interest. [pmid: 16919008].
Lupi-Herrera E, Sandoval J, Figueroa J, et al. Left and right ventricular power: outputs are the strongest hemodynamic correlates to allow identification of acute responders to vasodilator treatment in idiopathic pulmonary arterial hypertension. Arch Cardiol Mex. 2011;81(2):100-107. Exclude - No comparisons of interest. [pmid: 21775243].
MacGregor AJ, Canavan R, Knight C, et al. Pulmonary hypertension in systemic sclerosis: risk factors for progression and consequences for survival. Rheumatology (Oxford). 2001;40(4):453-9. Exclude - No study population of interest. [pmid: 11312386].
Machado C, Brito I, Souza D, et al. Etiological frequency of pulmonary hypertension in a reference outpatient clinic in Bahia, Brazil. Arq Bras Cardiol. 2009;93(6):629-36. 679. 86. Exclude - Does not include intervention of interest. [pmid: 20379644].
Machado RF, Barst RJ, Yovetich NA, et al. Hospitalization for pain in patients with sickle cell disease treated with sildenafil for elevated TRV and low exercise capacity. Blood. 2011;118(4):855-64. Exclude - No study population of interest. [pmid: 21527519].
Machado RF, Hildesheim M, Mendelsohn L, et al. NT-pro brain natriuretic peptide levels and the risk of death in the cooperative study of sickle cell disease. Br J Haematol. 2011;154(4):512-20. Exclude - no primary or secondary outcomes of interest. [pmid: 21689089].
Machado RF, Mack AK, Martyr S, et al. Severity of pulmonary hypertension during vaso-occlusive pain crisis and exercise in patients with sickle cell disease. Br J Haematol. 2007;136(2):319-25. Exclude - Does not include intervention of interest. [pmid: 17156401].
Machado RF, Martyr S, Kato GJ, et al. Sildenafil therapy in patients with sickle cell disease and pulmonary hypertension. Br J Haematol. 2005;130(3):445-53. Exclude - No comparisons of interest. [pmid: 16042696].
Machherndl S, Kneussl M, Baumgartner H, et al. Long-term treatment of pulmonary hypertension with aerosolized iloprost. Eur Respir J. 2001;17(1):8-13. Exclude - No comparisons of interest. [pmid: 11307761].
Maeda NY, Carvalho JH, Otake AH, et al. Platelet protease-activated receptor 1 and membrane expression of P-selectin in pulmonary arterial hypertension. Thromb Res. 2010;125(1):38-43. Exclude - Does not include intervention of interest. [pmid: 19447475].
Magne J, Lancellotti P, Pierard LA. Exercise pulmonary hypertension in asymptomatic degenerative mitral regurgitation. Circulation. 2010;122(1):33-41. Exclude - No study population of interest. [pmid: 20566950].
Mahmud E, Raisinghani A, Keramati S, et al. Dilation of the coronary sinus on echocardiogram: prevalence and significance in patients with chronic pulmonary hypertension. J Am Soc Echocardiogr. 2001;14(1):44-9. Exclude - no primary or secondary outcomes of interest. [pmid: 11174433].
Mainguy V, Maltais F, Saey D, et al. Effects of a rehabilitation program on skeletal muscle function in idiopathic pulmonary arterial hypertension. J Cardiopulm Rehabil Prev. 2010;30(5):319-23. Exclude - Does not include intervention of interest. [pmid: 20410828].
Maisel AS, Nakao K, Ponikowski P, et al. Japanese-Western consensus meeting on biomarkers. Int Heart J. 2011;52(5):253-65. Exclude - Not a full publication. [pmid: 22008432].
Maiya S, Hislop AA, Flynn Y, et al. Response to bosentan in children with pulmonary hypertension. Heart. 2006;92(5):664-70. Exclude - No comparisons of interest. [pmid: 16216850].
Malerba M, Radaeli A, Ragnoli B, et al. Exhaled nitric oxide levels in systemic sclerosis with and without pulmonary involvement. Chest. 2007;132(2):575-80. Exclude - No study population of interest. [pmid: 17550935].
Malhotra R, Hess D, Lewis GD, et al. Vasoreactivity to inhaled nitric oxide with oxygen predicts long-term survival in pulmonary arterial hypertension. Pulm Circ. 2011;1(2):250-258. Exclude - Does not include intervention of interest. [pmid: 22020367].
Malik AS, Warshafsky S, Lehrman S. Long-term nifedipine treatment for pulmonary hypertension: A meta-analysis. Cardiol Rev. 1998;15(1):35-40. Exclude - Background SR/MA.
Malinovschi A, Henrohn D, Eriksson A, et al. Increased plasma and salivary nitrite and decreased bronchial contribution to exhaled NO in pulmonary arterial hypertension. Eur J Clin Invest. 2011;41(8):889-97. Exclude - no primary or secondary outcomes of interest. [pmid: 21554268].
Mancano MA. New drugs of 2007. Pharm Times. 2008;74(3):75-82. Exclude - Not a full publication.
Manno RL, Wigley FM, Gelber AC, et al. Late-age onset systemic sclerosis. J Rheumatol. 2011;38(7):1317-25. Exclude - no primary or secondary outcomes of interest. [pmid: 21685299].
Martischnig AM, Tichy A, Nikfardjam M, et al. Inhaled iloprost for patients with precapillary pulmonary hypertension and right-side heart failure. J Card Fail. 2011;17(10):813-818. Exclude - No comparisons of interest. [pmid: 21962419].
Marvisi M, Brianti M, Marani G, et al. Hyperthyroidism and pulmonary hypertension. Respir Med. 2002;96(4):215-20. Exclude - No comparisons of interest. [pmid: 11999999].
Masri FA, Comhair SA, Dostanic-Larson I, et al. Deficiency of lung antioxidants in idiopathic pulmonary arterial hypertension. Clin Transl Sci. 2008;1(2):99-106. Exclude - Does not include intervention of interest. [pmid: 20443830].
Mathai SC, Girgis RE, Fisher MR, et al. Addition of sildenafil to bosentan monotherapy in pulmonary arterial hypertension. Eur Respir J. 2007;29(3):469-75. Exclude - No comparisons of interest. [pmid: 17079256].
Mathai SC, Girgis RE, Fisher MR, et al. Additon of sildenafil to bosentan monotherapy in pulmonary arterial hypertension. Eur Respir J. 2007;29(3):469-475. Exclude - No comparisons of interest. [pmid: 17079256].
Mathai SC, Hummers LK, Champion HC, et al. Survival in pulmonary hypertension associated with the scleroderma spectrum of diseases: impact of interstitial lung disease. Arthritis Rheum. 2009;60(2):569-77. Exclude - Does not include intervention of interest. [pmid: 19180517].
Mathewson HS. Selective drug therapy for pulmonary hypertension. Respir Care. 1995;40(8):871-875. Exclude - Not a full publication.
Mattuzzi S, Barbi S, Carletto A, et al. Association of polymorphisms in the IL1B and IL2 genes with susceptibility and severity of systemic sclerosis. J Rheumatol. 2007;34(5):997-1004. Exclude - Does not include intervention of interest. [pmid: 17444587].
Mazhar J, Pera V, Liang M, et al. How good is tricuspid regurgitation velocity in excluding pulmonary hypertension in patients with left heart disease. Heart Lung Circul. 2011;20:S176. Exclude - Not a full publication.
Mazurek JA, Salamon J, Zolty R. Endothelin-1 levels in pulmonary hypertension: A comparison between pulmonary arterial hypertension and diastolic heart failure-induced pulmonary hypertension. J Am Coll Cardiol. 2012;59(13):E1617. Exclude - Not a full publication.
Mazurek JA, Salamon JN, Kelesidis I, et al. Endothelin-1 levels in pulmonary hypertension: A comparison between pulmonary arterial hypertension and diastolic heart failure-induced pulmonary hypertension. J Heart Lung Transplant. 2012;31(4):S214-S215. Exclude - Not a full publication.
McCann GP, Gan CT, Beek AM, et al. Extent of MRI delayed enhancement of myocardial mass is related to right ventricular dysfunction in pulmonary artery hypertension. AJR Am J Roentgenol. 2007;188(2):349-55. Exclude - no primary or secondary outcomes of interest. [pmid: 17242241].
McConnell J, Nathan S, Hobbs K, et al. A multicenter, retrospective study of patients with pulmonary arterial hypertension who received inhaled iloprost for more than one year. Chest. 2011;140(4). Exclude - Not a full publication.
McConnell MV, Solomon SD, Rayan ME, et al. Regional right ventricular dysfunction detected by echocardiography in acute pulmonary embolism. Am J Cardiol. 1996;78(4):469-73. Exclude - No study population of interest. [pmid: 8752195].
McGoldrick S. Pivotal protocols. Good Clin Pract J. 2007;14(12):18-21. Exclude - Not a full publication.
McGoon MD, Frost AE, Oudiz RJ, et al. Ambrisentan therapy in patients with pulmonary arterial hypertension who discontinued bosentan or sitaxsentan due to liver function test abnormalities. Chest. 2009;135(1):122-9. Exclude - No comparisons of interest. [pmid: 18812445].
McLaughlin VV. Survival in patients with pulmonary arterial hypertension treated with first-line bosentan. Eur J Clin Invest. Suppl 3. 2006;36:10-5. Exclude – No comparisons of interest. [pmid: 16919005].
McLaughlin VV, Archer SL, Badesch DB, et al. A report of the american college of cardiology foundation task force on expert consensus documents and the american heart association. Circulation. 2009;119(16):2250-2294. Exclude - Background SR/MA. [pmid: 19332472].
McLaughlin VV, Genthner DE, Panella MM, et al. Reduction in pulmonary vascular resistance with long-term epoprostenol (prostacyclin) therapy in primary pulmonary hypertension. N Engl J Med. 1998;338(5):273-7. Exclude - no comparisons of interest. [pmid: 9445406].
McLaughlin VV, Shillington A, Rich S. Survival in primary pulmonary hypertension: the impact of epoprostenol therapy. Circulation. 2002;106(12):1477-82. Exclude - No comparisons of interest. [pmid: 12234951].
McLaughlin VV, Sitbon O, Badesch DB, et al. Survival with first-line bosentan in patients with primary pulmonary hypertension. Eur Respir J. 2005;25(2):244-9. Exclude - no comparisons of interest. [pmid: 15684287].
McLure LE, Brown A, Lee WN, et al. Non-invasive stroke volume measurement by cardiac magnetic resonance imaging and inert gas rebreathing in pulmonary hypertension. Clin Physiol Funct Imaging. 2011;31(3):221-6. Exclude - Does not include intervention of interest. [pmid: 21470362].
Meadows CA, Risbano MG, Zhang L, et al. Increased expression of growth differentiation factor-15 in systemic sclerosis-associated pulmonary arterial hypertension. Chest. 2011;139(5):994-1002. Exclude - Does not include intervention of interest. [pmid: 20829333].
Mealy NE, Bayes M, Del Fresno M. Bosentan: Treatment of pulmonary hypertension, treatment of heart failure, antihypertensive, endothelin ETA/ETB antagonist. Drugs Future. 2001;26(12):1149-1154. Exclude - Not a full publication.
Mehari A, Tian X, Alam S, et al. Hemodynamic parameters predict mortality in sickle cell disease-related pulmonary hypertension. Blood. 2010;116(21). Exclude - Not a full publication.
Mehta NJ, Khan IA, Mehta RN, et al. HIV-Related pulmonary hypertension: analytic review of 131 cases. Chest. 2000;118(4):1133-41. Exclude - Not a full publication. [pmid: 11035689].
Mekontso Dessap A, Leon R, Habibi A, et al. Pulmonary hypertension and cor pulmonale during severe acute chest syndrome in sickle cell disease. Am J Respir Crit Care Med. 2008;177(6):646-53. Exclude - no primary or secondary outcomes of interest. [pmid: 18174543].
Melenovsky V, Al-Hiti H, Kazdova L, et al. Transpulmonary B-type natriuretic peptide uptake and cyclic guanosine monophosphate release in heart failure and pulmonary hypertension: the effects of sildenafil. J Am Coll Cardiol. 2009;54(7):595-600. Exclude - No study population of interest. [pmid: 19660688].
Melgosa MT, Ricci GL, Garcia-Pagan JC, et al. Acute and long-term effects of inhaled iloprost in portopulmonary hypertension. Liver Transpl. 2010;16(3):348-56. Exclude - No comparisons of interest. [pmid: 20209595].
Melnick L, Barst RJ, Rowan CA, et al. Effectiveness of transition from intravenous epoprostenol to oral/inhaled targeted pulmonary arterial hypertension therapy in pediatric idiopathic and familial pulmonary arterial hypertension. Am J Cardiol. 2010;105(10):1485-9. Exclude - No comparisons of interest. [pmid: 20451700].
Meng J, Li ZX, Jiang W, et al. Relationship of serum ADMA with pulmonary hypertension in patients on hemodialysis. Dial Transplant. 2010;39(6):242-246. Exclude - No study population of interest.
Menon N, McAlpine L, Peacock AJ, et al. The acute effects of prostacyclin on pulmonary hemodynamics in patients with pulmonary hypertension secondary to systemic sclerosis. Arthritis Rheum. 1998;41(3):466-9. Exclude - No comparisons of interest. [pmid: 9506575].
Menzel T, Kramm T, Bruckner A, et al. Quantitative assessment of right ventricular volumes in severe chronic thromboembolic pulmonary hypertension using transthoracic three-dimensional echocardiography: changes due to pulmonary thromboendarterectomy. Eur J Echocardiogr. 2002;3(1):67-72. Exclude - No study population of interest. [pmid: 12067537].
Menzel T, Kramm T, Mohr-Kahaly S, et al. Assessment of cardiac performance using Tei indices in patients undergoing pulmonary thromboendarterectomy. Ann Thorac Surg. 2002;73(3):762-6. Exclude - No study population of interest. [pmid: 11899179].
Menzel T, Kramm T, Wagner S, et al. Improvement of tricuspid regurgitation after pulmonary thromboendarterectomy. Ann Thorac Surg. 2002;73(3):756-61. Exclude - No study population of interest. [pmid: 11899178].
Menzel T, Wagner S, Kramm T, et al. Pathophysiology of impaired right and left ventricular function in chronic embolic pulmonary hypertension: changes after pulmonary thromboendarterectomy. Chest. 2000;118(4):897-903. Exclude - No study population of interest. [pmid: 11035654].
Merce J, Ferras S, Oltra C, et al. Cardiovascular abnormalities in hyperthyroidism: a prospective Doppler echocardiographic study. Am J Med. 2005;118(2):126-31. Exclude - No comparisons of interest. [pmid: 15694895].
Meune C, Avouac J, Gobeaux C, et al. Ultra sensitive troponin in systemic sclerosis. Arthritis Rheum. 2011;63(10). Exclude - Not a full publication.
Meune C, Avouac J, Gobeaux C, et al. Ultra sensitive troponin in SSc. Rheumatology (Oxford). 2012;51:ii111. Exclude - Not a full publication.
Michelakis ED, Tymchak W, Noga M, et al. Long-term treatment with oral sildenafil is safe and improves functional capacity and hemodynamics in patients with pulmonary arterial hypertension. Circulation. 2003;108(17):2066-9. Exclude - No comparisons of interest. [pmid: 14568893].
Mikhail G, Gibbs J, Richardson M, et al. An evaluation of nebulized prostacyclin in patients with primary and secondary pulmonary hypertension. Eur Heart J. 1997;18(9):1499-504. Exclude - No study population of interest. [pmid: 9458458].
Mikhail GW, Prasad SK, Li W, et al. Clinical and haemodynamic effects of sildenafil in pulmonary hypertension: acute and mid-term effects. Eur Heart J. 2004;25(5):431-6. Exclude - No comparisons of interest. [pmid: 15033256].
Miller SK. Pulsed Doppler echocardiographic measurement of pulmonary acceleration time in diagnosing patients with pulmonary hypertension. J Diagn Med Sonogr. 1995;11(5):241-245. Exclude - No comparisons of interest.
Milman N, Burton CM, Iversen M, et al. Pulmonary hypertension in end-stage pulmonary sarcoidosis: therapeutic effect of sildenafil?. J Heart Lung Transplant. 2008;27(3):329-34. Exclude - No study population of interest. [pmid: 18342757].
Mingo S, Garcia Lunar I, Monivas V, et al. Right ventricular 2D strain: A new echocardiographic prognostic factor for mortality in pulmonary hypertension. Eur Heart J. 2011;32:437. Exclude - Not a full publication. [pmid: 21118851].
Mininni S, Vono R, Diricatti G, et al. Exercise doppler echocardiography: A new approach in the evaluation of pulmonary artery disease. Cardiovasc Imaging. 1996;8(2):323-326. Exclude - no primary or secondary outcomes of interest.
Minniti CP, Sable C, Campbell A, et al. Elevated tricuspid regurgitant jet velocity in children and adolescents with sickle cell disease: association with hemolysis and hemoglobin oxygen desaturation. Haematologica. 2009;94(3):340-7. Exclude - Does not include intervention of interest. [pmid: 19211639].
Mistry PK, Sirrs S, Chan A, et al. Pulmonary hypertension in type 1 Gaucher’s disease: genetic and epigenetic determinants of phenotype and response to therapy. Mol Genet Metab. 2002;77(1–2):91-8. Exclude - no primary or secondary outcomes of interest. [pmid: 12359135].
Mitoff PR, Burwash I, De Kemp RJ, et al. Right ventricle glucose metabolism and pressure overload in patients with pulmonary arterial hypertension. J Card Fail. 2011;17(8):S16. Exclude - Not a full publication.
Moazami N, Oz MC. Natriuretic peptides in the perioperative management of cardiac surgery patients. Heart Surg Forum. 2005;8(3):141-147. Exclude - Not a full publication.
Moceri P, Dimopoulos K, Liodakis E, et al. Echocardiographic predictors of outcome in eisenmenger syndrome. J Am Coll Cardiol. 2012;59(13):E795. Exclude - Not a full publication.
Modrykamien AM, Gudavalli R, McCarthy K, et al. Echocardiography, 6-minute walk distance, and distance-saturation product as predictors of pulmonary arterial hypertension in idiopathic pulmonary fibrosis. Respir Care. 2010;55(5):584-8. Exclude - No study population of interest. [pmid: 20420729].
Mogollon Jimenez MV, Escoresca Ortega AM, Cabeza Letran ML, et al. Correlation of echocardiographic and hemodynamic parameters in pulmonary hypertension assessment prior to heart transplantation. Transplant Proc. 2008;40(9):3023-4. Exclude - No study population of interest. [pmid: 19010179].
Mogollon Jimenez MV, Escoresca Ortega AM, Hinojosa Perez R, et al. Comparison between two drugs on the hemodynamic evaluation of pulmonary hypertension prior to heart transplantation. Transplant Proc. 2008;40(9):3009-11. Exclude - No study population of interest. [pmid: 19010174].
Mohamed WA, Ismail M. A randomized, double-blind, placebo-controlled, prospective study of bosentan for the treatment of persistent pulmonary hypertension of the newborn. J Perinatol. 2011. Exclude - no study population of interest. [pmid: 22076415].
Mohan N. Importance of screening and early detection of pulmonary hypertension and current treatment options. J Postgrad Med. 2005;51(2):107. Exclude - Not a full publication.
Mok MY, Cheung BM, Lo Y, et al. Elevated plasma adrenomedullin and vascular manifestations in patients with systemic sclerosis. J Rheumatol. 2007;34(11):2224-9. Exclude - Does not include intervention of interest. [pmid: 17937467].
Mok MY, Tsang PL, Lam YM, et al. Bosentan use in systemic lupus erythematosus patients with pulmonary arterial hypertension. Lupus. 2007;16(4):279-85. Exclude - No comparisons of interest. [pmid: 17439935].
Molaei A, Aarabi Mogaddam MY, Davari PN, et al. Validity of sildenafil test in patients with pulmonary arterial hypertension associated with congenital heart disease according to clinical and echocardiographic parameters. J Tehran Uni Heart Cent. 2009;4(2):103-108. Exclude - No comparisons of interest.
Moledina S, Hislop AA, Foster H, et al. Childhood idiopathic pulmonary arterial hypertension: a national cohort study. Heart. 2010;96(17):1401-6. Exclude - no comparisons of interest. [pmid: 20406768].
Monahan K, Hickson D, Butler K, et al. Distribution and determinants of pulmonary artery systolic pressure in african-americans: The jackson heart study. Circulation. 2011;124(21). Exclude - Not a full publication.
Monfredi O, Griffiths L, Clarke B, et al. Efficacy and safety of Bosentan for pulmonary arterial hypertension in adults with congenital heart disease. Am J Cardiol. 2011;108(10):1483-8. Exclude - No comparisons of interest. [pmid: 21943933].
Montani D, Savale L, Natali D, et al. Long-term response to calcium-channel blockers in non-idiopathic pulmonary arterial hypertension. Eur Heart J. 2010;31(15):1898-907. Exclude - Background Other. [pmid: 20543192].
Morales-Blanhir J, Santos S, de Jover L, et al. Clinical value of vasodilator test with inhaled nitric oxide for predicting long-term response to oral vasodilators in pulmonary hypertension. Respir Med. 2004;98(3):225-34. Exclude - no primary or secondary outcomes of interest. [pmid: 15002758].
Morelli S, Ferri C, Polettini E, et al. Plasma endothelin-1 levels, pulmonary hypertension, and lung fibrosis in patients with systemic sclerosis. Am J Med. 1995;99(3):255-60. Exclude - no primary or secondary outcomes of interest. [pmid: 7653485].
Mori S, Nakatani S, Kanzaki H, et al. Patterns of the interventricular septal motion can predict conditions of patients with pulmonary hypertension. J Am Soc Echocardiogr. 2008;21(4):386-93. Exclude - no primary or secondary outcomes of interest. [pmid: 17681728].
Morikawa T, Murata M, Okuda S, et al. Quantitative analysis of right ventricular function in patients with pulmonary hypertension using three-dimensional echocardiography and a two-dimensional summation method compared to magnetic resonance imaging. Am J Cardiol. 2011;107(3):484-9. Exclude - No comparisons of interest. [pmid: 21257019].
Morris CR, Kato GJ, Poljakovic M, et al. Dysregulated arginine metabolism, hemolysis-associated pulmonary hypertension, and mortality in sickle cell disease. JAMA. 2005;294(1):81-90. Exclude - Does not include intervention of interest. [pmid: 15998894].
Morsy MF, Alnajjar AA, Almuzainy IS, et al. Splenectomized versus non-splenectomized patients with thalassemia major. Echocardiographic comparison. Saudi Med J. 2008;29(9):1310-4. Exclude - no primary or secondary outcomes of interest. [pmid: 18813418].
Motiwala A, Fatimi SH, Akhtar N, et al. Patients with congenital atrial septal defects: effect of age at repair and defect size on pulmonary artery pressures prior to repair. Thorac Cardiovasc Surg. 2011;59(5):281-6. Exclude - no primary or secondary outcomes of interest. [pmid: 21412709].
Motoji Y, Tanaka H, Fukuda Y, et al. Utility of rightventricular free wall longitudinal speckle tracking strain for evaluation of outcome in patients with pulmonary hypertension. J Am Soc Echocardiogr. 2012;25(6):B102. Exclude - Not a full publication.
Mourani PM, Sontag MK, Ivy DD, et al. Effects of long-term sildenafil treatment for pulmonary hypertension in infants with chronic lung disease. J Pediatr. 2009;154(3):379-84. 384 e1. 2. Exclude - No comparisons of interest. [pmid: 18950791].
Moustapha A, Kaushik V, Diaz S, et al. Echocardiographic evaluation of left-ventricular diastolic function in patients with chronic pulmonary hypertension. Cardiology. 2001;95(2):96-100. Exclude - no primary or secondary outcomes of interest. [pmid: 11423714].
Moustapha A, Lim M, Saikia S, et al. Interrogation of the tricuspid annulus by Doppler tissue imaging in patients with chronic pulmonary hypertension: implications for the assessment of right-ventricular systolic and diastolic function. Cardiology. 2001;95(2):101-4. Exclude - no primary or secondary outcomes of interest. [pmid: 11423715].
Mukerjee D, St George D, Coleiro B, et al. Prevalence and outcome in systemic sclerosis associated pulmonary arterial hypertension: application of a registry approach. Ann Rheum Dis. 2003;62(11):1088-93. Exclude - no primary or secondary outcomes of interest. [pmid: 14583573].
Mulligan C, Beghetti M. Inhaled iloprost for the control of acute pulmonary hypertension in children: A systematic review. Pediatr Crit Care Med. 2011. Exclude - Background SR/MA. [pmid: 21926655].
Muneer A, Ralph DJ, Minhas S. Sildenafil citrate (Viagra(trademark)). J Drug Eval. 2003;1(7):225-246. Exclude - Not a full publication.
Murase M, Ishida A. Serial pulsed Doppler assessment of pulmonary artery pressure in very low birth-weight infants. Pediatr Cardiol. 2000;21(5):452-7. Exclude - No study population of interest. [pmid: 10982705].
Murata I, Sonoda M, Morita T, et al. The clinical significance of reversed flow in the main pulmonary artery detected by doppler color flow imaging. Chest. 2000;118(2):336-41. Exclude - no primary or secondary outcomes of interest. [pmid: 10936121].
Mussivand T. Multidisciplinary congress in cardio-thoracic healthcare. August 17–20, 2006. 16th World Congress of the World Society of Cardio-Thoracic surgeons. Ottawa, Canada. Future Cardiol. 2006;2(6):647-650. Exclude - Not a full publication.
Mychaskiw MA, Berger A, Mardekian J, et al. Methods for estimating health-state utilities in pulmonary arterial hypertension. Value Health. 2010;13(7):A361. Exclude - Not a full publication.
Mychaskiw MA, Berger A, Mardekian J, et al. Patterns of therapy, health care utilization, and health care costs in patients with pulmonary arterial hypertension (PAH) initiating therapy with sildenafil: Findings from retrospective analyses of administrative health care claims data. Value Health. 2010;13(7):A351. Exclude - Not a full publication.
Myers SA, Ahearn GS, Angelica Selim M, et al. Cutaneous findings in patients with pulmonary arterial hypertension receiving long-term epoprostenol therapy. J Am Acad Dermatol. 2004;51(1):98-102. Exclude - No comparisons of interest. [pmid: 15243533].
Myers SN, Nouraie M, Minniti C, et al. Clinical manifestations of high and low degrees of hemolysis in children with SCD. Am J Hematol. 2010;85(8):E29-E30. Exclude - Not a full publication.
Naderi N, Ojaghi Haghighi SZ, Amin A, et al. Utility of right ventricular strain imaging in predicting pulmonary vascular resistance in patients with pulmonary hypertension. J Am Coll Cardiol. 2012;59(13):E1608. Exclude - Not a full publication.
Nadrous HF, Pellikka PA, Krowka MJ, et al. Pulmonary hypertension in patients with idiopathic pulmonary fibrosis. Chest. 2005;128(4):2393-9. Exclude - No study population of interest. [pmid: 16236900].
Nagaya N, Satoh T, Uematsu M, et al. Shortening of Doppler-derived deceleration time of early diastolic transmitral flow in the presence of pulmonary hypertension through ventricular interaction. Am J Cardiol. 1997;79(11):1502-6. Exclude - Does not include intervention of interest. [pmid: 9185641].
Nagaya N, Shimizu Y, Satoh T, et al. Oral beraprost sodium improves exercise capacity and ventilatory efficiency in patients with primary or thromboembolic pulmonary hypertension. Heart. 2002;87(4):340-5. Exclude - No comparisons of interest. [pmid: 11907007].
Nagaya N, Uematsu M, Okano Y, et al. Effect of orally active prostacyclin analogue on survival of outpatients with primary pulmonary hypertension. J Am Coll Cardiol. 1999;34(4):1188-92. Exclude - Does not include intervention of interest. [pmid: 10520811].
Nakahata Y, Hiraishi S, Oowada N, et al. Quantitative assessment of pulmonary vascular resistance and reactivity in children with pulmonary hypertension due to congenital heart disease using a noninvasive method: new Doppler-derived indexes. Pediatr Cardiol. 2009;30(3):232-9. Exclude - Does not include intervention of interest. [pmid: 18956135].
Nakamura K, Miyahara Y, Ikeda S, et al. Assessment of right ventricular diastolic function by pulsed Doppler echocardiography in chronic pulmonary disease and pulmonary thromboembolism. Respiration. 1995;62(5):237-43. Exclude - No study population of interest. [pmid: 8560088].
Nakhoul F, Yigla M, Gilman R, et al. The pathogenesis of pulmonary hypertension in haemodialysis patients via arterio-venous access. Nephrol Dial Transplant. 2005;20(8):1686-92. Exclude - No study population of interest. [pmid: 15840664].
Nakwan N, Wannaro J. Persistent pulmonary hypertension of the newborn successfully treated with beraprost sodium: a retrospective chart review. Neonatology. 2011;99(1):32-7. Exclude - No comparisons of interest. [pmid: 20588068].
Namachivayam P, Theilen U, Butt WW, et al. Sildenafil prevents rebound pulmonary hypertension after withdrawal of nitric oxide in children. Am J Respir Crit Care Med. 2006;174(9):1042-7. Exclude - No study population of interest. [pmid: 16917115].
Narvaez David R, Dorantes G J, Hernandez RP, et al. Preliminary report of acute pharmacological effect of sildenafil in pulmonary hypertension of several causes. Med Interna Mex. 2006;22(4):292-296. Exclude - Not available in English.
Nathan SD, Shlobin OA, Barnett SD, et al. Right ventricular systolic pressure by echocardiography as a predictor of pulmonary hypertension in idiopathic pulmonary fibrosis. Respir Med. 2008;102(9):1305-10. Exclude - No study population of interest. [pmid: 18619825].
Nef HM, Tiede H, Moellmann H, et al. Diagnostic value of plasma soluble FMS-like tyrosine kinase-1 (SFLT) and placental growth factor (PLGF) in patients with dyspnea: Results from the Biosphere-II study. Eur Heart J. 2011;32:434-435. Exclude - Not a full publication.
Neil E, Ruth A, Rod H. Neonatal outcomes following the introduction of a time-metered nitric oxide delivery system. J Paediatr Child Health. 2012;48:33. Exclude - Not a full publication.
Nelson SC, Adade BB, McDonough EA, et al. High prevalence of pulmonary hypertension in children with sickle cell disease. J Pediatr Hematol Oncol. 2007;29(5):334-7. Exclude - No comparisons of interest. [pmid: 17483714].
Nemoto S, Sasaki T, Ozawa H, et al. Oral sildenafil for persistent pulmonary hypertension early after congenital cardiac surgery in children. Eur J Cardiothorac Surg. 2010;38(1):71-7. Exclude - No comparisons of interest. [pmid: 20206543].
Neuhofer W. Method for diagnosis of a disease involving an anti-endothelin receptor antibody. Expert Opin Med Diagn. 2008;2(7):875-878. Exclude - Not a full publication. [pmid: 23495823].
Neuman Y, Kotliroff A, Bental T, et al. Pulmonary artery pressure and diastolic dysfunction in normal left ventricular systolic function. Int J Cardiol. 2008;127(2):174-8. Exclude - No study population of interest. [pmid: 17643534].
Newman JH, Kar S, Kirkpatrick P. Ambrisentan Nat Rev Drug Discov. 2007;6(9):697-8. Exclude - Not a full publication. [pmid: 17907344].
Ng C, Franklin O, Vaidya M, et al. Adenosine infusion for the management of persistent pulmonary hypertension of the newborn. Pediatr Crit Care Med. 2004;5(1):10-3. Exclude - Does not include intervention of interest. [pmid: 14697102].
Ngian G, Nikpour M, Byron J, et al. Survival in Australian patients with connective tissue disease-associated pulmonary arterial hypertension. Intern Med J. 2011;41:12. Exclude - Not a full publication.
Ngian GS, Stevens W, Byron J, et al. Survival and predictors of mortality in australian patients with connective tissue disease-associated pulmonary arterial hypertension. Arthritis Rheum. 2011;63(10). Exclude - Not a full publication.
Nicholl R. Nitric oxide in preterm babies. Arch Dis Child. 2002;86(1):59-60. Exclude - Not a full publication. [pmid: 11806888].
Nishimura E, Ikeda S, Naito T, et al. Evaluation of right-ventricular function by Doppler echocardiography in patients with chronic respiratory failure. J Int Med Res. 1999;27(2):65-73. Exclude - No study population of interest. [pmid: 10446692].
Noori S, Friedlich P, Wong P, et al. Cardiovascular effects of sildenafil in neonates and infants with congenital diaphragmatic hernia and pulmonary hypertension. Neonatology. 2007;91(2):92-100. Exclude - No study population of interest. [pmid: 17344658].
Nootens M, Kaufmann E, Rich S. Short-term effectiveness of nifedipine in secondary pulmonary hypertension. Am J Cardiol. 1993;71(16):1475-6. Exclude – does not include intervention of interest. [pmid: 8517404].
Nootens M, Schrader B, Kaufmann E, et al. Comparative acute effects of adenosine and prostacyclin in primary pulmonary hypertension. Chest. 1995;107(1):54-7. Exclude - Does not include intervention of interest. [pmid: 7813311].
Nouraie M, Barst RJ, Rosenzweig EB, et al. NT-proBNP as a marker of cardiopulmonary compromise and exercise limitation in adults with sickle cell anemia in the walk-phasst study. Blood. 2010;116(21). Exclude - Not a full publication.
Nunes H, Humbert M, Sitbon O, et al. Prognostic factors for survival in human immunodeficiency virus-associated pulmonary arterial hypertension. Am J Respir Crit Care Med. 2003;167(10):1433-9. Exclude - No comparisons of interest. [pmid: 12615632].
Nyp M, Sandritter T, Poppinga N, et al. Sildenafil citrate, bronchopulmonary dysplasia and disordered pulmonary gas exchange: any benefits?. J Perinatol. 2011. Exclude - No comparisons of interest.
O’Callaghan DS, Rich J, Thenappan T. From NT-proBNP as a survival parameter to left-sided heart failure, and more: 6 Months in pulmonary hypertension. Int J Clin Pract. 2007;61(SUPPL 156):32-43. Exclude - Not a full publication. [pmid: 17229178].
Ochikubo CG, Waffarn F, Turbow R, et al. Echocardiographic evidence of improved hemodynamics during inhaled nitric oxide therapy for persistent pulmonary hypertension of the newborn. Pediatr Cardiol. 1997;18(4):282-7. Exclude - Does not include intervention of interest. [pmid: 9175525].
Oelberg DA, Marcotte F, Kreisman H, et al. Evaluation of right ventricular systolic pressure during incremental exercise by Doppler echocardiography in adults with atrial septal defect. Chest. 1998;113(6):1459-65. Exclude - Does not include intervention of interest. [pmid: 9631778].
Ogawa A, Matsubara H, Fujio H, et al. Risk of alveolar hemorrhage in patients with primary pulmonary hypertension--anticoagulation and epoprostenol therapy. Circ J. 2005;69(2):216-20. Exclude - No comparisons of interest. [pmid: 15671616].
Ohashi M, Sato K, Suzuki S, et al. Doppler echocardiographic evaluation of latent pulmonary hypertension by passive leg raising. Coron Artery Dis. 1997;8(10):651-5. Exclude - No study population of interest. [pmid: 9457447].
Ohno Y, Koyama H, Nogami M, et al. Dynamic perfusion MRI: capability for evaluation of disease severity and progression of pulmonary arterial hypertension in patients with connective tissue disease. J Magn Reson Imaging. 2008;28(4):887-99. Exclude - Does not include intervention of interest. [pmid: 18821609].
Okano Y, Yoshioka T, Shimouchi A, et al. Short-term effect of continuous intravenous prostacyclin (Epoprostenol) in patients with primary pulmonary hypertension. Respir Circ. 1997;45(1):73-79. Exclude - not available in English.
Olschewski H, Ghofrani HA, Schmehl T, et al. Inhaled iloprost to treat severe pulmonary hypertension. An uncontrolled trial. German PPH Study Group Ann Intern Med. 2000;132(6):435-43. Exclude - No comparisons of interest. [pmid: 10733442].
Olschewski H, Walmrath D, Schermuly R, et al. Aerosolized prostacyclin and iloprost in severe pulmonary hypertension. Ann Intern Med. 1996;124(9):820-4. Exclude - Does not include intervention of interest. [pmid: 8610951].
Olson TP, Snyder EM, Frantz RP, et al. Repeat length polymorphism of the serotonin transporter gene influences pulmonary artery pressure in heart failure. Am Heart J. 2007;153(3):426-32. Exclude - No study population of interest. [pmid: 17307423].
Omar HA, Gong F, Sun MY, et al. Nebulized nitroglycerin in children with pulmonary hypertension secondary to congenital heart disease. W V Med J. 1999;95(2):74-5. Exclude - Does not include intervention of interest. [pmid: 10214095].
Omelyanovsky V, Avxentyeva M, Krysanov I, et al. Cost-effectiveness analysis of bosentan and sildenafil compared with standard therapy in treatment of primary pulmonary arterial hypertension in Russian Federation. Value Health. 2011;14(7):A367. Exclude - Not a full publication.
Ono F, Nagaya N, Kyotani S, et al. Hemodynamic and hormonal effects of beraprost sodium, an orally active prostacyclin analogue, in patients with secondary precapillary pulmonary hypertension. Circ J. 2003;67(5):375-8. Exclude - no comparisons of interest. [pmid: 12736472].
Opitz CF, Wensel R, Bettmann M, et al. Assessment of the vasodilator response in primary pulmonary hypertension. Comparing prostacyclin and iloprost administered by either infusion or inhalation. Eur Heart J. 2003;24(4):356-65. Exclude - no primary or secondary outcomes of interest. [pmid: 12581683].
Opitz CF, Wensel R, Winkler J, et al. Clinical efficacy and survival with first-line inhaled iloprost therapy in patients with idiopathic pulmonary arterial hypertension. Eur Heart J. 2005;26(18):1895-902. Exclude - No comparisons of interest. [pmid: 15888496].
Orfanos SE, Psevdi E, Stratigis N, et al. Pulmonary capillary endothelial dysfunction in early systemic sclerosis. Arthritis Rheum. 2001;44(4):902-11. Exclude - no primary or secondary outcomes of interest. [pmid: 11315930].
Otterdal K, Andreassen AK, Yndestad A, et al. Raised LIGHT levels in pulmonary arterial hypertension: potential role in thrombus formation. Am J Respir Crit Care Med. 2008;177(2):202-7. Exclude - Does not include intervention of interest. [pmid: 17962639].
Oudiz R, Allard M, Blair C, et al. Ambrisentan therapy in patients with pulmonary arterial hypertension: 3-year outcome. Chest. 2011;140(4). Exclude - Not a full publication.
Oudiz R, Shapiro S, Torres F, et al. Athena-1: Hemodynamic improvements following the addition of ambrisentan to background pde5I therapy in patients with pulmonary arterial hypertension. Chest. 2011;140(4). Exclude - Not a full publication.
Oudiz RJ, Roveran G, Hansen JE, et al. Effect of sildenafil on ventilatory efficiency and exercise tolerance in pulmonary hypertension. Eur J Heart Fail. 2007;9(9):917-21. Exclude - No comparisons of interest. [pmid: 17707133].
Oudiz RJ, Schilz RJ, Barst RJ, et al. Treprostinil, a prostacyclin analogue, in pulmonary arterial hypertension associated with connective tissue disease. Chest. 2004;126(2):420-7. Exclude - No comparisons of interest. [pmid: 15302727].
Oudiz RJ, Widlitz A, Beckmann XJ, et al. Micrococcus-associated central venous catheter infection in patients with pulmonary arterial hypertension. Chest. 2004;126(1):90-4. Exclude - No comparisons of interest. [pmid: 15249447].
Owens AT, Jessup M. The year in heart failure. J Am Coll Cardiol. 2011;57(15):1573-83. Exclude - Not a full publication. [pmid: 21474036].
Ozawa T, Ninomiya Y, Honma T, et al. Increased serum angiotensin I-converting enzyme activity in patients with mixed connective tissue disease and pulmonary hypertension. Scand J Rheumatol. 1995;24(1):38-43. Exclude - no primary or secondary outcomes of interest. [pmid: 7863277].
Ozkan M, Dweik RA, Laskowski D, et al. High levels of nitric oxide in individuals with pulmonary hypertension receiving epoprostenol therapy. Lung. 2001;179(4):233-43. Exclude - no primary or secondary outcomes of interest. [pmid: 11891614].
Pabst S, Hammerstingl C, Schwarze-Zander C, et al. Prevalence of pulmonary arterial hypertension in the HIV cohort of the University Bonn: Results of the PAHIBO study. Eur Heart J. 2011;32:116. Exclude - Not a full publication.
Palii I, Vataman E, Maniuc L, et al. Clinical and haemodynamic effects of sidenafil in pulmonary hypertension secondary congenital systemic-to-pulmonary shunts and RV disfunction. Eur Heart J. 2011;32:113. Exclude - Not a full publication.
Parikh R, Scherzer R, Nitta E, et al. Asymmetric dimethylarginine levels are associated with pulmonary arterial hypertension in HIV-infected individuals. J Am Coll Cardiol. 2012;59(13):E1614. Exclude - Not a full publication.
Park MM, Lundgrin EL, Sharp J, et al. Right ventricular global longitudinal strain by two-dimensional speckle tracking echocardiography correlates with conventional echocardiographic determinants of severity in pulmonary hypertension. J Am Soc Echocardiogr. 2012;25(6):B104. Exclude - Not a full publication.
Park MM, Park JH, Sharp J, et al. Compatibility of strain with speckle tracking echocardiography and velocityvector imaging in detection of adverse clinical outcomes in patients with pulmonary arterial hypertension. J Am Soc Echocardiogr. 2012;25(6):B11. Exclude - Not a full publication.
Pashankar F, Manwani D, Lee M, et al. Effect of hydroxyurea on elevated pulmonary artery pressures in children with sickle cell disease. Blood. 2011;118(21). Exclude - Not a full publication.
Patel N, Mills JF, Cheung MM. Assessment of right ventricular function using tissue Doppler imaging in infants with pulmonary hypertension. Neonatology. 2009;96(3):193-9. discussion 200–2. Exclude - Does not include intervention of interest. [pmid: 19407463].
Payvandi LA, Burri MV, Gupta D, et al. Can 2-dimensional echocardiography provide accurate assessments of right ventricular volume and systolic function in patients with pulmonary hypertension?. Circulation. 2011;124(21). Exclude - Not a full publication.
Pendergrass SA, Hayes E, Farina G, et al. Limited systemic sclerosis patients with pulmonary arterial hypertension show biomarkers of inflammation and vascular injury. PLoS One. 2010;5(8):e12106. Exclude - no primary or secondary outcomes of interest. [pmid: 20808962].
Peoples C, Domsic RT, Medsger TA, et al. Pulmonary hypertension assessment and recognition of outcomes in scleroderma: Racial differences in systemic sclerosis-related pulmonary hypertension. Arthritis Rheum. 2011;63(10). Exclude - Not a full publication.
Perez VAdJ, Rosenzweig E, Rubin LJ, et al. Safety and Efficacy of Transition from Systemic Prostanoids to Inhaled Treprostinil in Pulmonary Arterial Hypertension. Am J Cardiol. 2012. Exclude - No comparisons of interest.
Perez-Penate GM, Julia-Serda G, Ojeda-Betancort N, et al. Long-term inhaled nitric oxide plus phosphodiesterase 5 inhibitors for severe pulmonary hypertension. J Heart Lung Transplant. 2008;27(12):1326-32. Exclude - No comparisons of interest. [pmid: 19059113].
Perkins JD. Diagnosing hepatopulmonary syndrome. Liver Transplant. 2007;13(10):1464-1465. Exclude - Background Other.
Perkins JD. Screening for portopulmonary hypertension: Comments. Liver Transplant. 2007;13(3):463-464. Exclude - Background Other.
Peterson AL, Deatsman S, Frommelt MA, et al. Correlation of echocardiographic markers and therapy in persistent pulmonary hypertension of the newborn. Pediatr Cardiol. 2009;30(2):160-5. Exclude - Does not include intervention of interest. [pmid: 18779989].
Petkov V, Ziesche R, Mosgoeller W, et al. Aerosolised iloprost improves pulmonary haemodynamics in patients with primary pulmonary hypertension receiving continuous epoprostenol treatment. Thorax. 2001;56(9):734-6. Exclude - no primary or secondary outcomes of interest. [pmid: 11514696].
Pignone A, Mori F, Pieri F, et al. Exercise Doppler echocardiography identifies preclinic asymptomatic pulmonary hypertension in systemic sclerosis. Ann N Y Acad Sci. 2007;1108:291-304. Exclude - No study population of interest. [pmid: 17893993].
Piranfar MA, Karvandi M, Tofigh AM. Intracardiac shunts and role of tissue Doppler imaging in diagnosis and discrimination. J Tehran Uni Heart Cent. 2008;3(2):95-100. Exclude - no primary or secondary outcomes of interest.
Plastiras SC, Karadimitrakis SP, Kampolis C, et al. Determinants of pulmonary arterial hypertension in scleroderma. Semin Arthritis Rheum. 2007;36(6):392-6. Exclude - no primary or secondary outcomes of interest. [pmid: 17204309].
Pope JE, Lee P, Baron M, et al. Prevalence of elevated pulmonary arterial pressures measured by echocardiography in a multicenter study of patients with systemic sclerosis. J Rheumatol. 2005;32(7):1273-8. Exclude - No comparisons of interest. [pmid: 15996064].
Popovtzer B, Salamon JN, Mazurek J, et al. Mortality in primary pulmonary arterial hypertension stratified by hemoglobin levels. J Card Fail. 2011;17(8):S96. Exclude - Not a full publication.
Porhownik NR, Al-Sharif H, Bshouty Z. Addition of sildenafil in patients with pulmonary arterial hypertension with inadequate response to bosentan monotherapy. Can Respir J. 2008;15(8):427-30. Exclude - no comparisons of interest. [pmid: 19107243].
Preston I, Ishizawar D, Burger C, et al. Transition from inhaled to parenteral treprostinil in selected patients with pulmonary arterial hypertension. Chest. 2011;140(4). Exclude - Not a full publication.
Preston IR, Klinger JR, Houtches J, et al. Acute and chronic effects of sildenafil in patients with pulmonary arterial hypertension. Respir Med. 2005;99(12):1501-10. Exclude - no primary or secondary outcomes of interest. [pmid: 15890512].
Preston IR, Klinger JR, Landzberg MJ, et al. Vasoresponsiveness of sarcoidosis-associated pulmonary hypertension. Chest. 2001;120(3):866-72. Exclude - No study population of interest. [pmid: 11555522].
Provencher S, Herve P, Sitbon O, et al. Changes in exercise haemodynamics during treatment in pulmonary arterial hypertension. Eur Respir J. 2008;32(2):393-8. Exclude - No comparisons of interest. [pmid: 18417516].
Puchalski MD, Lozier JS, Bradley DJ, et al. Electrocardiography in the diagnosis of right ventricular hypertrophy in children. Pediatrics. 2006;118(3):1052-5. Exclude - Does not include intervention of interest. [pmid: 16950997].
Pulido T, Sandoval J, Roquet I, et al. Interaction of acenocoumarol and sitaxentan in pulmonary arterial hypertension. Eur J Clin Invest. Suppl 2. 2009;39:14-8. Exclude - No comparisons of interest. [pmid: 19335742].
Pyxaras S, Valentincic M, Perkan A, et al. Echocardiographic evaluation of systolic and mean pulmonary artery pressure in the follow-up of patients with pulmonary hypertension. G Ital Cardiol. 2011;12(5):75S. Exclude - Not a full publication.
Quarck R, Durand H, Ninio E, et al. Platelet-activating factor acetylhydrolase (PAF-AH): A predictor of adverse event in medically treated CTEPH patients?. J Heart Lung Transplant. 2012;31(4):S61. Exclude - Not a full publication.
Quarck R, Nawrot T, Meyns B, et al. C-reactive protein: a new predictor of adverse outcome in pulmonary arterial hypertension. J Am Coll Cardiol. 2009;53(14):1211-8. Exclude - Does not include intervention of interest. [pmid: 19341863].
Qureshi N, Joyce JJ, Qi N, et al. Right ventricular abnormalities in sickle cell anemia: evidence of a progressive increase in pulmonary vascular resistance. J Pediatr. 2006;149(1):23-7. Exclude - no primary or secondary outcomes of interest. [pmid: 16860121].
Rabasseda X. Therapies for heart failure: a report from the Heart Failure Congress 2007. Timely Top Med Cardiovasc Dis. 2007;11:E16. Exclude - unable to obtain full-text. [pmid: 18297144].
Raffy O, Azarian R, Brenot F, et al. Clinical significance of the pulmonary vasodilator response during short-term infusion of prostacyclin in primary pulmonary hypertension. Circulation. 1996;93(3):484-8. Exclude - no primary or secondary outcomes of interest. [pmid: 8565165].
Raimondi F, Migliaro F, Capasso L, et al. Intravenous magnesium sulphate vs. inhaled nitric oxide for moderate, persistent pulmonary hypertension of the newborn. A Multicentre, retrospective study. J Trop Pediatr. 2008;54(3):196-9. Exclude - Does not include intervention of interest. [pmid: 18048460].
Raja SG, Danton MD, MacArthur KJ, et al. Treatment of pulmonary arterial hypertension with sildenafil: from pathophysiology to clinical evidence. J Cardiothorac Vasc Anesth. 2006;20(5):722-35. Exclude - Background SR/MA. [pmid: 17023298].
Raja SG, Danton MD, MacArthur KJ, et al. Effects of escalating doses of sildenafil on hemodynamics and gas exchange in children with pulmonary hypertension and congenital cardiac defects. J Cardiothorac Vasc Anesth. 2007;21(2):203-7. Exclude - no primary or secondary outcomes of interest. [pmid: 17418732].
Rajagopalan N, Simon MA, Mathier MA, et al. Identifying right ventricular dysfunction with tissue Doppler imaging in pulmonary hypertension. Int J Cardiol. 2008;128(3):359-63. Exclude - no primary or secondary outcomes of interest. [pmid: 17714807].
Ranjan S, Hall T, Huynh L, et al. Echocardiographic indices of right ventricular function as predictors of severity of pulmonary arterial hypertension. Heart Lung Circul. 2011;20:S172. Exclude - Not a full publication.
Ranu H, Connell E, Hunt C, et al. Elevated tricuspid regurgitation jet velocity on echocardiogram in patients with sickle cell disease is associated with worse steady state functional class, poor lung function and low haemoglobin but not other markers of haemolysis or endothelin-1. Blood. 2010;116(21). Exclude - Not a full publication.
Reichenberger F, Mainwood A, Doughty N, et al. Effects of nebulised iloprost on pulmonary function and gas exchange in severe pulmonary hypertension. Respir Med. 2007;101(2):217-22. Exclude - No comparisons of interest. [pmid: 16831539].
Reichenberger F, Voswinckel R, Schulz R, et al. Noninvasive detection of early pulmonary vascular dysfunction in scleroderma. Respir Med. 2009;103(11):1713-8. Exclude - No study population of interest. [pmid: 19497725].
Reichenberger F, Voswinckel R, Steveling E, et al. Sildenafil treatment for portopulmonary hypertension. Eur Respir J. 2006;28(3):563-7. Exclude - No comparisons of interest. [pmid: 16807265].
Reynolds EW, Ellington JG, Vranicar M, et al. Brain-type natriuretic peptide in the diagnosis and management of persistent pulmonary hypertension of the newborn. Pediatrics. 2004;114(5):1297-304. Exclude - no primary or secondary outcomes of interest. [pmid: 15520111].
Rich S. The effects of vasodilators in pulmonary hypertension: pulmonary vascular or peripheral vascular?. Circ Heart Fail. 2009;2(2):145-50. Exclude - Not a full publication. [pmid: 19808330].
Riedel B, Lim J, Brauer K, et al. Diagnosis and management of persistent pulmonary thromboembolism. J Cardiothorac Vasc Anesth. 2006;20(4):616-9. Exclude - Not a full publication. [pmid: 16885000].
Rimensberger PC, Spahr-Schopfer I, Berner M, et al. Inhaled nitric oxide versus aerosolized iloprost in secondary pulmonary hypertension in children with congenital heart disease: vasodilator capacity and cellular mechanisms. Circulation. 2001;103(4):544-8. Exclude - no primary or secondary outcomes of interest. [pmid: 11157720].
Robbins IM, Barst RJ, Rubin LJ, et al. Increased levels of prostaglandin D(2) suggest macrophage activation in patients with primary pulmonary hypertension. Chest. 2001;120(5):1639-44. Exclude - no primary or secondary outcomes of interest. [pmid: 11713147].
Roberts JD Jr, Fineman JR, Morin FC 3rd, et al. Inhaled nitric oxide and persistent pulmonary hypertension of the newborn. The Inhaled Nitric Oxide Study Group N Engl J Med. 1997;336(9):605-10. Exclude - Does not include intervention of interest. [pmid: 9032045].
Roberts KE, Fallon MB, Krowka MJ, et al. Serotonin transporter polymorphisms in patients with portopulmonary hypertension. Chest. 2009;135(6):1470-5. Exclude - Does not include intervention of interest. [pmid: 19141529].
Roca GQ, Campbell P, Barst R, et al. Right ventricular longitudinal strain correlates with cardiopulmonary hemodynamics and nt-probnp in pulmonary arterial hypertension. J Am Coll Cardiol. 2012;59(13):E1285. Exclude - Not a full publication.
Rocha G, Baptista MJ, Guimaraes H. Persistent pulmonary hypertension of non cardiac cause in a neonatal intensive care unit. Pulmonary Medicine. 2012. Exclude - No study population of interest.
Roeleveld RJ, Vonk-Noordegraaf A, Marcus JT, et al. Effects of epoprostenol on right ventricular hypertrophy and dilatation in pulmonary hypertension. Chest. 2004;125(2):572-9. Exclude - no primary or secondary outcomes of interest. [pmid: 14769740].
Rolla G, Colagrande P, Scappaticci E, et al. Exhaled nitric oxide in systemic sclerosis: relationships with lung involvement and pulmonary hypertension. J Rheumatol. 2000;27(7):1693-8. Exclude - no primary or secondary outcomes of interest. [pmid: 10914853].
Roman A, Rodes-Cabau J, Lara B, et al. Clinic-hemodynamic study and treatment of 44 patients with primary pulmonary hypertension. Med Clin. 2002;118(20):761-766. Exclude - Not available in English.
Rondelet B, Dewachter L, Kerbaul F, et al. Sildenafil added to sitaxsentan in overcirculation-induced pulmonary arterial hypertension. Am J Physiol Heart Circ Physiol. 2010;299(4):H1118-23. Exclude - Not a full publication. [pmid: 20693396].
Rosenzweig EB, Ivy DD, Widlitz A, et al. Effects of long-term bosentan in children with pulmonary arterial hypertension. J Am Coll Cardiol. 2005;46(4):697-704. Exclude - No comparisons of interest. [pmid: 16098438].
Rosenzweig EB, Kerstein D, Barst RJ. Long-term prostacyclin for pulmonary hypertension with associated congenital heart defects. Circulation. 1999;99(14):1858-65. Exclude - No comparisons of interest. [pmid: 10199883].
Roushdy A, Ragab I, Raout WA. Noninvasive assessment of elevated pulmonary vascular resistance in children with pulmonary hypertension secondary to congenital heart disease. Comparative study between 5 different doppler indices. J Am Soc Echocardiogr. 2012;25(6):B98. Exclude - Not a full publication.
Rubens C, Ewert R, Halank M, et al. Big endothelin-1 and endothelin-1 plasma levels are correlated with the severity of primary pulmonary hypertension. Chest. 2001;120(5):1562-9. Exclude - no primary or secondary outcomes of interest. [pmid: 11713135].
Rubin L, Parikh K, Pulido T, et al. Freedom-M: Efficacy and safety of oral treprostinil diethanolamine as monotherapy in patients with pulmonary arterial hypertension. Chest. 2011;140(4). Exclude - Not a full publication.
Ruiz MJ, Escribano P, Delgado JF, et al. Efficacy of sildenafil as a rescue therapy for patients with severe pulmonary arterial hypertension and given long-term treatment with prostanoids: 2-year experience. J Heart Lung Transplant. 2006;25(11):1353-7. Exclude - No comparisons of interest. [pmid: 17097500].
Rutter N. Echocardiography for the neonatologist. Curr Paediatr. 1999;9(2):128-131. Exclude - Background Other.
Saadjian AY, Paganelli F, Gaubert ML, et al. Adenosine plasma concentration in pulmonary hypertension. Cardiovasc Res. 1999;43(1):228-36. Exclude - no primary or secondary outcomes of interest. [pmid: 10536708].
Sablotzki A, Czeslick E, Gruenig E, et al. First experiences with the stable prostacyclin analog iloprost in the evaluation of heart transplant candidates with increased pulmonary vascular resistance. J Thorac Cardiovasc Surg. 2003;125(4):960-2. Exclude - No study population of interest. [pmid: 12698166].
Sachdev A, Villarraga HR, Frantz RP, et al. Right ventricular strain for prediction of survival in patients with pulmonary arterial hypertension. Chest. 2011;139(6):1299-309. Exclude - Does not include intervention of interest. [pmid: 21148241].
Sachdev V, Kato GJ, Gibbs JS, et al. Echocardiographic markers of elevated pulmonary pressure and left ventricular diastolic dysfunction are associated with exercise intolerance in adults and adolescents with homozygous sickle cell anemia in the United States and United Kingdom. Circulation. 2011;124(13):1452-60. Exclude - no primary or secondary outcomes of interest. [pmid: 21900080].
Sadushi-Kolici R, Jakowitsch J, Skoro-Sajer N, et al. Plasma levels of soluble P-selectin predict survival in chronic thromboembolic pulmonary hypertension. Journal fur Kardiologie. 2011;18(5–6):196. Exclude - Not a full publication.
Sadushi-Kolici R, Skoro-Sajer N, Zimmer D, et al. Long-term treatment, tolerability and survival with subcutaneous treprostinil for severe pulmonary hypertension. Journal fur Kardiologie. 2011;18(5–6):196. Exclude - Not a full publication.
Safdar Z. Treatment of pulmonary arterial hypertension: the role of prostacyclin and prostaglandin analogs. Respir Med. 2011;105(6):818-27. Exclude - Not a full publication. [pmid: 21273054].
Saggar R, Derhovanessian A, Fields AV, et al. ‘Notching’ of the right ventricular outflow tract Doppler profile (DopplerRVOT) is a highly sensitive and specific predictor of pulmonary vascular disease among patients with systemic sclerosis. J Heart Lung Transplant. 2012;31(4):S68. Exclude - Not a full publication.
Sahni J. Revatio (sildenafil citrate) for the treatment of pulmonary arterial hypertension. Conn Med. 2006;70(6):381-3. Exclude - Not a full publication. [pmid: 16869470].
Saji T, Ozawa Y, Ishikita T, et al. Short-term hemodynamic effect of a new oral PGI2 analogue, beraprost, in primary and secondary pulmonary hypertension. Am J Cardiol. 1996;78(2):244-7. Exclude - Does not include intervention of interest. [pmid: 8712155].
Salgado M, Madeira L, Theilacker L, et al. Prevalence of pulmonary hypertension in SSc: Correlation with clinical form. Rheumatology (Oxford). 2012;51:ii65. Exclude - Not a full publication.
Sanchez O, Marcos E, Perros F, et al. Role of endothelium-derived CC chemokine ligand 2 in idiopathic pulmonary arterial hypertension. Am J Respir Crit Care Med. 2007;176(10):1041-7. Exclude - Does not include intervention of interest. [pmid: 17823354].
Sandoval J, Bauerie O, Palomar A, et al. Survival in primary pulmonary hypertension. Validation of a prognostic equation. Circulation. 1994;89(4):1733-44. Exclude – does not include intervention of interest. [pmid: 8149539].
Sandoval J, Gaspar J, Pena H, et al. Effect of atrial septostomy on the survival of patients with severe pulmonary arterial hypertension. Eur Respir J. 2011;38(6):1343-1348. Exclude - Does not include intervention of interest. [pmid: 21349914].
Sasayama S. Treatment of pulmonary hypertension with Bosentan. Respir Circ. 2003;51(9):901-907. Exclude - Not available in English.
Saxena N, Rajagopalan N, Edelman K, et al. Tricuspid annular systolic velocity: a useful measurement in determining right ventricular systolic function regardless of pulmonary artery pressures. Echocardiography. 2006;23(9):750-5. Exclude - no primary or secondary outcomes of interest. [pmid: 16999693].
Sbarouni E, Georgiadou P, Manginas A, et al. Ischaemia-modified albumin in pulmonary hypertension. Biomarkers. 2010;15(3):238-42. Exclude - Does not include intervention of interest. [pmid: 19995310].
Schattke S, Knebel F, Grohmann A, et al. Early right ventricular systolic dysfunction in patients with systemic sclerosis without pulmonary hypertension: a Doppler Tissue and Speckle Tracking echocardiography study. Cardiovasc Ultrasound. 2010;8:3. Exclude - No study population of interest. [pmid: 20096122].
Schenk P, Madl C, Kramer L, et al. Acute vasodilator testing in primary and secondary pulmonary hypertension. Wien Klin Wochenschr. 2001;113(13–14):496-503. Exclude - no primary or secondary outcomes of interest.
Scholzel BE, Post MC, Thijs Plokker HW, et al. Clinical worsening during long-term follow-up in inoperable chronic thromboembolic pulmonary hypertension. Lung. 2012;190(2):161-7. Exclude - No study population of interest. [pmid: 22160210].
Schulze-Neick I, Uhlemann F, Nurnberg JH, et al. Aerolized prostacyclin for preoperative evaluation and postoperative treatment of patients with pulmonary hypertension. Z Kardiol. 1997;86(2):71-80. Exclude - Not available in English. [pmid: 9173700].
Schwaiblmair M, Faul C, von Scheidt W, et al. Influence of specific drug therapy on cardiopulmonary exercise testing parameters in patients with pulmonary hypertension. Appl Cardiopulm Pathophysiol. 2011;15(2):71-80. Exclude - Does not include intervention of interest.
Schwartz BG, Kloner RA. Drug interactions with phosphodiesterase-5 inhibitors used for the treatment of erectile dysfunction or pulmonary hypertension. Circulation. 2010;122(1):88-95. Exclude - Not a full publication. [pmid: 20606131].
Scott JP, Higenbottam T, Wallwork J. The acute effect of the synthetic prostacyclin analogue iloprost in primary pulmonary hypertension. Br J Clin Pract. 1990;44(6):231-4. Exclude – does not include intervention of interest. [pmid: 1698429].
Sehgal A. Ultrasound features of pulmonary hypertension: Audit and review of literature. J Paediatr Child Health. 2012;48:156. Exclude - Not a full publication.
Selimovic N, Bergh CH, Andersson B, et al. Growth factors and interleukin-6 across the lung circulation in pulmonary hypertension. Eur Respir J. 2009;34(3):662-8. Exclude - Does not include intervention of interest. [pmid: 19324949].
Serra W, Chetta A, Santilli D, et al. Echocardiography may help detect pulmonary vasculopathy in the early stages of pulmonary artery hypertension associated with systemic sclerosis. Cardiovasc Ultrasound. 2010;8:25. Exclude - No study population of interest. [pmid: 20598164].
Seyfarth HJ, Pankau H, Hammerschmidt S, et al. Bosentan improves exercise tolerance and Tei index in patients with pulmonary hypertension and prostanoid therapy. Chest. 2005;128(2):709-13. Exclude - No comparisons of interest. [pmid: 16100158].
Shah AA, Chung SE, Wigley FM, et al. The value of periodic echocardiography screening to detect pulmonary hypertension and predict mortality in scleroderma. Arthritis Rheum. 2011;63(10). Exclude - Not a full publication.
Shah AA, Mayer S, Girgis R, et al. Correlation between exercise echocardiography and right heart catheterization in scleroderma patients at risk for pulmonary hypertension. Arthritis Rheum. 2011;63(10). Exclude - Not a full publication.
Sharma S, Kadali R, Daggubati R, et al. Pulmonary artery occlusion pressure may overdiagnose pulmonary artery hypertension in sickle cell disease. Chest. 2011;140(4). Exclude - Not a full publication.
Shen J, He B, Wang B. Effects of lipo-prostaglandin E1 on pulmonary hemodynamics and clinical outcomes in patients with pulmonary arterial hypertension. Chest. 2005;128(2):714-9. Exclude - Does not include intervention of interest. [pmid: 16100159].
Shen JY, Yao TB, Liu H, et al. Diagnosis and differentiation of pulmonary arterial hypertension through an algorithm based on right heart catheterisation. Heart. 2011;97:A228. Exclude - Not a full publication.
Shen Y, Wen F. Inaccuracy of doppler echocardiography diagnoses mild congenital heart disease related pulmonary hypertension. Heart. 2011;97:A156-A157. Exclude - Not a full publication.
Shiina Y, Funabashi N, Lee K, et al. Right atrium contractility and right ventricular diastolic function assessed by pulsed tissue Doppler imaging can predict brain natriuretic peptide in adults with acquired pulmonary hypertension. Int J Cardiol. 2009;135(1):53-9. Exclude - No study population of interest. [pmid: 18793807].
Shirai Y, Yasuoka H, Takeuchi T, et al. Long-term outcomes of patients with pulmonary arterial hypertension and connective tissue disease treated with intravenous epoprostenol. Rheumatology (Oxford). 2012;51:ii60-ii61. Exclude - Not a full publication.
Shuster J. Various adverse effects and behaviors associated with sildenafil; Another case of glycemic control problems associated with fluoroquinolone therapy; The first case of pure white cell aplasia in a patient treated with imipenem-cilastatin; High-output heart failure associated with anagrelide; Renal dysfunction attributed to oral acyclovir therapy. Hosp Pharm. 2005;40(10):848-852. Exclude - Not a full publication.
Simon MA, Deible C, Mathier MA, et al. Phenotyping the right ventricle in patients with pulmonary hypertension. Clin Transl Sci. 2009;2(4):294-9. Exclude - no primary or secondary outcomes of interest. [pmid: 20443908].
Simon MA, Rajagopalan N, Mathier MA, et al. Tissue Doppler imaging of right ventricular decompensation in pulmonary hypertension. Congest Heart Fail. 2009;15(6):271-6. Exclude - no primary or secondary outcomes of interest. [pmid: 19925505].
Singh R, Choudhury M, Saxena A, et al. Inhaled nitroglycerin versus inhaled milrinone in children with congenital heart disease suffering from pulmonary artery hypertension. J Cardiothorac Vasc Anesth. 2010;24(5):797-801. Exclude - Does not include intervention of interest. [pmid: 20056439].
Sirithanakul K, Mubarak KK. Pulmonary arterial hypertension: new treatments are improving outcomes. J Fam Pract. 2004;53(12):959-69. Exclude - Not a full publication. [pmid: 15581438].
Sitbon O, Humbert M, Nunes H, et al. Long-term intravenous epoprostenol infusion in primary pulmonary hypertension: prognostic factors and survival. J Am Coll Cardiol. 2002;40(4):780-8. Exclude - No comparisons of interest. [pmid: 12204511].
Sitbon O, McLaughlin VV, Badesch DB, et al. Survival in patients with class III idiopathic pulmonary arterial hypertension treated with first line oral bosentan compared with an historical cohort of patients started on intravenous epoprostenol. Thorax. 2005;60(12):1025-30. Exclude - no comparisons of interest. [pmid: 16055621].
Sivasli E, Yurdakok M, Karagoz T, et al. Inhaled iloprost to treat neonatal pulmonary hypertension. Cocuk Sagligi Hast Derg. 2005;48(2):142-146. Exclude - Not available in English.
Skrok J, Shehata ML, Mathai S, et al. Pulmonary arterial hypertension: MR imaging-derived first-pass bolus kinetic parameters are biomarkers for pulmonary hemodynamics, cardiacfunction, and ventricular remodeling. Radiology. 2012;263(3):678-687. Exclude - Does not include intervention of interest. [pmid: 22509050].
Smadja DM, Gaussem P, Mauge L, et al. Circulating endothelial cells: a new candidate biomarker of irreversible pulmonary hypertension secondary to congenital heart disease. Circulation. 2009;119(3):374-81. Exclude - no primary or secondary outcomes of interest. [pmid: 19139384].
Smadja DM, Mauge L, Sanchez O, et al. Distinct patterns of circulating endothelial cells in pulmonary hypertension. Eur Respir J. 2010;36(6):1284-93. Exclude - Does not include intervention of interest. [pmid: 20413531].
Smrzova A, Horak P, Skacelova M, et al. Pulmonary hypertension in patients with systemic scleroderma, mixed ctd, localize scleroderma and primary RP. Rheumatology (Oxford). 2012;51:ii121. Exclude - Not a full publication.
Song JW, Song JK, Kim DS. Echocardiography and brain natriuretic peptide as prognostic indicators in idiopathic pulmonary fibrosis. Respir Med. 2009;103(2):180-6. Exclude - No study population of interest. [pmid: 19097877].
Song ZZ, Ma J. Right ventricular function evaluated by quantitative tissue velocity imaging and cardiac catheterization in pulmonary artery hypertension patients. Chin J Med Imaging Technol. 2007;23(5):686-688. Exclude - Not available in English.
Sood BG, Delaney-Black V, Glibetic M, et al. PGE2/TXB2 imbalance in neonatal hypoxemic respiratory failure. Acta Paediatr Int J Paediatr. 2007;96(5):669-673. Exclude - No study population of interest.
Sood BG, Wykes S, Landa M, et al. Expression of eNOS in the lungs of neonates with pulmonary hypertension. Exp Mol Pathol. 2011;90(1):9-12. Exclude - Does not include intervention of interest. [pmid: 21111729].
Soon E, Holmes AM, Treacy CM, et al. Elevated levels of inflammatory cytokines predict survival in idiopathic and familial pulmonary arterial hypertension. Circulation. 2010;122(9):920-7. Exclude - Does not include intervention of interest. [pmid: 20713898].
SoRelle R. Report From the 93rd Cardiovascular and Renal Drugs Advisory Committee Meeting. August 9–10, 2001. Circulation. 2001;104(9):E9017-8. [pmid: 11526948]. Exclude - Not a full publication.
Souza R, Bogossian HB, Humbert M, et al. N-terminal-pro-brain natriuretic peptide as a haemodynamic marker in idiopathic pulmonary arterial hypertension. Eur Respir J. 2005;25(3):509-13. Exclude - no primary or secondary outcomes of interest. [pmid: 15738296].
Souza R, Jardim C, Martins B, et al. Effect of bosentan treatment on surrogate markers in pulmonary arterial hypertension. Curr Med Res Opin. 2005;21(6):907-11. Exclude - No comparisons of interest. [pmid: 15969891].
Stackhouse KA, Devendra G, Hart S, et al. Right ventricular size and function and its change over time independently predict survival in pulmonary hypertension. J Heart Lung Transplant. 2012;31(4):S80. Exclude - Not a full publication.
Stasch JP, Pacher P, Evgenov OV. Soluble guanylate cyclase as an emerging therapeutic target in cardiopulmonary disease. Circulation. 2011;123(20):2263-73. Exclude - Not a full publication. [pmid: 21606405].
Steen V, Medsger TA Jr. Predictors of isolated pulmonary hypertension in patients with systemic sclerosis and limited cutaneous involvement. Arthritis Rheum. 2003;48(2):516-22. Exclude - Does not include intervention of interest. [pmid: 12571862].
Stefanantoni K, Sciarra I, Iannace N, et al. SSc with and without pulmonary arterial hypertension compared to idiopathic pulmonary arterial hypertension different behaviour of some angiogenetic biomarkers. Rheumatology (Oxford). 2012;51:ii116. Exclude - Not a full publication.
Stefanidis A, Koutroulis G, Kollias G, et al. Role of Echocardiography in the Diagnosis and Follow-up of Patients with Pulmonary Arterial and Chronic Thromboembolic Pulmonary Hypertension. Hell J Cardiol. 2004;45(1):48-56. Exclude - Background Other.
Steringer-Mascherbauer R, Eder V, Huber C, et al. Transitioning from subcutaneous to intravenous treprostinil administered by the implantable infusion pump Lenuspro(registered trademark): A single-center pilot study. Journal fur Kardiologie. 2012;19(5–6):153. Exclude - Not a full publication.
Stocker C, Penny DJ, Brizard CP, et al. Intravenous sildenafil and inhaled nitric oxide: a randomised trial in infants after cardiac surgery. Intensive Care Med. 2003;29(11):1996-2003. Exclude - Does not include intervention of interest. [pmid: 14530859].
Stricker H, Domenighetti G, Popov W, et al. Severe pulmonary hypertension: data from the Swiss Registry. Swiss Med Wkly. 2001;131(23–24):346-50. Exclude - Does not include intervention of interest. [pmid: 11486567].
Strumpher J, Jacobsohn E. Pulmonary hypertension and right ventricular dysfunction: Physiology and perioperative management. J Cardiothorac Vasc Anesth. 2011;25(4):687-704. Exclude - Not a full publication. [pmid: 21620732].
Suleman N, Frost AE. Transition from epoprostenol and treprostinil to the oral endothelin receptor antagonist bosentan in patients with pulmonary hypertension. Chest. 2004;126(3):808-15. Exclude - no primary or secondary outcomes of interest. [pmid: 15364760].
Sulica R, Dinh HV, Dunsky K, et al. The acute hemodynamic effect of IV nitroglycerin and dipyridamole in patients with pulmonary arterial hypertension: comparison with IV epoprostenol. Congest Heart Fail. 2005;11(3):139-44. quiz 145–6. Exclude - Does not include intervention of interest. [pmid: 15947535].
Sulica R, Teirstein AS, Kakarla S, et al. Distinctive clinical, radiographic, and functional characteristics of patients with sarcoidosis-related pulmonary hypertension. Chest. 2005;128(3):1483-9. Exclude - No study population of interest. [pmid: 16162747].
Sun YJ, Xiong CM, Shan GL, et al. Inhaled low-dose iloprost for pulmonary hypertension: A prospective, multicenter, open-label study. Clin Cardiol. 2012;35(6):365-370. Exclude - No comparisons of interest. [pmid: 22488211].
Suntharalingam J, Hodgkins D, Cafferty FH, et al. Does rapid dose titration affect the hepatic safety profile of Bosentan?. Vascul Pharmacol. 2006;44(6):508-12. Exclude - No comparisons of interest. [pmid: 16713365].
Suntharalingam J, Hughes RJ, Goldsmith K, et al. Acute haemodynamic responses to inhaled nitric oxide and intravenous sildenafil in distal chronic thromboembolic pulmonary hypertension (CTEPH). Vascul Pharmacol. 2007;46(6):449-55. Exclude - No study population of interest. [pmid: 17368113].
Suntharalingam J, Treacy CM, Doughty NJ, et al. Long-term use of sildenafil in inoperable chronic thromboembolic pulmonary hypertension. Chest. 2008;134(2):229-36. Exclude - No study population of interest. [pmid: 18263674].
Swanson KL, Utz JP, Krowka MJ. Doppler echocardiography-right heart catheterization relationships in patients with idiopathic pulmonary fibrosis and suspected pulmonary hypertension. Med Sci Monit. 2008;14(4):CR177-82. Exclude - No study population of interest. [pmid: 18376344].
Sztajzel J, Ricou F, Jeanpretre M, et al. Right heart involvement in asymptomatic HIV patients: An outpatient study combining Doppler-echocardiography and radionuclide angiograph. J Noninvasive Cardiol. 1998;2(5):20-27. Exclude - No comparisons of interest.
Takahashi K, Mori Y, Yamamura H, et al. Effect of beraprost sodium on pulmonary vascular resistance in candidates for a Fontan procedure: a preliminary study. Pediatr Int. 2003;45(6):671-5. Exclude - No comparisons of interest. [pmid: 14651539].
Takahashi T, Sakuma M, Ikeda J, et al. Effects and problems of continuous infusion of epoprostenol for patients with primary pulmonary hypertension. Intern Med. 2002;41(10):784-8. Exclude - No comparisons of interest. [pmid: 12412996].
Talosi G, Katona M, Racz K, et al. Prostaglandin E1 treatment in patent ductus arteriosus dependent congenital heart defects. J Perinat Med. 2004;32(4):368-374. Exclude - No comparisons of interest. [pmid: 15346826].
Talwalkar JA, Swanson KL, Krowka MJ, et al. Prevalence of spontaneous portosystemic shunts in patients with portopulmonary hypertension and effect on treatment. Gastroenterology. 2011;141(5):1673-1679. Exclude - no primary or secondary outcomes of interest. [pmid: 21723219].
Tam NL, He XS. Clinical management of portopulmonary hypertension. Hepatobiliary Pancreat Dis Int. 2007;6(5):464-9. Exclude - Not a full publication. [pmid: 17897906].
Tanaka S, Hoshi K, Tanaka J, et al. Serum brain natriuretic peptide is a reliable marker for survival of pulmonary arterial hypertension associated with connective tissue diseases, including systemic sclerosis, mixed connective tissue disease and systemic lupus erythematosus. Arthritis Rheum. 2011;63(10). Exclude - Not a full publication.
Tanaseanu C, Tudor S, Tamsulea I, et al. Vascular endothelial growth factor, lipoporotein-associated phospholipase A2, sP-selectin and antiphospholipid antibodies, biological markers with prognostic value in pulmonary hypertension associated with chronic obstructive pulmonary disease and systemic lupus erithematosus. Eur J Med Res. 2007;12(4):145-51. Exclude - no primary or secondary outcomes of interest. [pmid: 17509958].
Tapson VF, Gomberg-Maitland M, McLaughlin VV, et al. Safety and efficacy of IV treprostinil for pulmonary arterial hypertension: a prospective, multicenter, open-label, 12-week trial. Chest. 2006;129(3):683-8. Exclude - No comparisons of interest. [pmid: 16537868].
Tapson VF, McLaughlin VV, Gomberg-Maitland M, et al. Delivery of intravenous treprostinil at low infusion rates using a miniaturized infusion pump in patients with pulmonary arterial hypertension. J Vasc Access. 2006;7(3):112-7. Exclude - No comparisons of interest. [pmid: 17019662].
Tarrass F, Benjelloun M, Medkouri G, et al. Doppler echocardiograph evaluation of pulmonary hypertension in patients undergoing hemodialysis. Hemodial Int. 2006;10(4):356-9. Exclude - no primary or secondary outcomes of interest. [pmid: 17014511].
Taveira-DaSilva AM, Hathaway OM, Sachdev V, et al. Pulmonary artery pressure in lymphangioleiomyomatosis: an echocardiographic study. Chest. 2007;132(5):1573-8. Exclude - No study population of interest. [pmid: 17890459].
Tavli T, Sekuri C, Goktalay T, et al. The acute effects of cilazapril on pulmonary function tests and arterial blood gas changes in patients with pulmonary hypertension. Int J Clin Pharmacol Res. 2003;23(2–3):53-9. Exclude - No study population of interest. [pmid: 15018019].
Tedford RJ, Hemnes AR, Russell SD, et al. PDE5A inhibitor treatment of persistent pulmonary hypertension after mechanical circulatory support. Circ Heart Fail. 2008;1(4):213-9. Exclude - No study population of interest. [pmid: 19808294].
Tegzova D, Ambroz D, Jansa P, et al. Possibilities of early detection of severe cardiovascular manifestations of SLE. Ceska Revmatol. 2007;15(3):131-141. Exclude - Not available in English.
Tegzova D, Kamenik L, Musilova L, et al. The incidence and course of pulmonary hypertension in systemic lupus erythematosus patients. Three years follow up outcome. Ceska Revmatol. 2003;11(3):117-127. Exclude - Not available in English.
Thai A, Addetia K, Langleben D, et al. Clinical utility of right ventricular end-diastolic wall stress in patients with pulmonary hypertension. J Am Soc Echocardiogr. 2012;25(6):B7. Exclude - Not a full publication.
Thakkar V, Patterson K, Stevens W, et al. Novel biomarkers of dysregulated angiogenesis are not specific to pulmonary arterial hypertension in SSc. Rheumatology (Oxford). 2012;51:ii28. Exclude - Not a full publication.
Thakkar V, Stevens W, Prior D, et al. N-terminal pro-brain natriuretic peptide levels predict incident pulmonary arterial hypertension in SSc. Rheumatology (Oxford). 2012;51:ii8. Exclude - Not a full publication.
Thenappan T, Palevsky HI. Long-term outcomes in pulmonary arterial hypertension. Int J Clin Pract. 2009;63(SUPPL 162):42-44. Exclude - Not a full publication.
Thurnheer R, Jenni R, Russi EW, et al. Hyperthyridism and pulmonary hypertension. J Intern Med. 1997;242(2):185-188. Exclude - Not a full publication. [pmid: 9279297].
Tillman O, Speich R. Primary pulmonary hypertension. Schweiz Med Wochenschr. 1997;127(22):923-934. Exclude - Not available in English. [pmid: 9289820].
Ting H, Sun XG, Chuang ML, et al. A noninvasive assessment of pulmonary perfusion abnormality in patients with primary pulmonary hypertension. Chest. 2001;119(3):824-32. Exclude - Does not include intervention of interest. [pmid: 11243964].
Tits G, Van den Brande P, Van Mieghem W, et al. Clinical and haemodynamic spectrum of primary pulmonary hypertension. Eur J Intern Med. 1998;9(3):165-170. Exclude - No comparisons of interest.
Tolsa JF, Cotting J, Sekarski N, et al. Magnesium sulphate as an alternative and safe treatment for severe persistent pulmonary hypertension of the newborn. Arch Dis Child Fetal Neonatal Ed. 1995;72(3):F184-7. Exclude - Does not include intervention of interest. [pmid: 7796235].
Tonelli AR, Plana JC, Heresi GA, et al. Prevalence and prognostic value of left ventricular diastolic dysfunction in idiopathic and heritable pulmonary arterial hypertension. Chest. 2012;141(6):1457-65. Exclude - no primary or secondary outcomes of interest. [pmid: 22207680].
Torielli F, Fashaw LM, Knudson O, et al. Echocardiographic outcome of infants treated as newborns with inhaled nitric oxide for severe hypoxemic respiratory failure. J Pediatr. 2001;138(3):349-54. Exclude - Does not include intervention of interest. [pmid: 11241041].
Torres Macho J, Delgado Jimenez JF, Sanz Salvo J, et al. Effect of different pharmacologic agents to reverse severe pulmonary hypertension among end-stage heart failure patients. Transplant Proc. 2009;41(6):2477-9. Exclude - No study population of interest. [pmid: 19715956].
Toshner MR, Gopalan D, Suntharalingam J, et al. Pulmonary arterial size and response to sildenafil in chronic thromboembolic pulmonary hypertension. J Heart Lung Transplant. 2010;29(6):610-5. Exclude - No study population of interest. [pmid: 20227301].
Trachte AL, Lobato EB, Urdaneta F, et al. Oral sildenafil reduces pulmonary hypertension after cardiac surgery. Ann Thorac Surg. 2005;79(1):194-7. discussion 194–7. Exclude - No study population of interest. [pmid: 15620942].
Tsiakalos A, Hatzis G, Moyssakis I, et al. Portopulmonary hypertension and serum endothelin levels in hospitalized patients with cirrhosis. Hepatobiliary Pancreat Dis Int. 2011;10(4):393-8. Exclude - Does not include intervention of interest. [pmid: 21813388].
Tsutsui JM, Maciel RR, Costa JM, et al. Hand-carried ultrasound performed at bedside in cardiology inpatient setting - A comparative study with comprehensive echocardiography. Cardiovasc Ultrasound. 2004;2. Exclude - No study population of interest.
Tuomi L. Drug therapy in primary pulmonary hypertension. J Cardpulm Rehabil. 1994;14(4):224-227. Exclude – not a full publication.
Turanlahti M, Pesonen E, Pohjavuori M, et al. Plasma cyclic guanosine monophosphate reflecting the severity of persistent pulmonary hypertension of the newborn. Biol Neonate. 2001;80(2):107-12. Exclude - no primary or secondary outcomes of interest. [pmid: 11509809].
Turanlahti MI, Laitinen PO, Sarna SJ, et al. Nitric oxide, oxygen, and prostacyclin in children with pulmonary hypertension. Heart. 1998;79(2):169-74. Exclude - Does not include intervention of interest. [pmid: 9538311].
Ulett KB, Marwick TH. Incorporation of pulmonary vascular resistance measurement into standard echocardiography: implications for assessment of pulmonary hypertension. Echocardiography. 2007;24(10):1020-2. Exclude - no primary or secondary outcomes of interest. [pmid: 18001353].
Ulrich S, Fischler M, Speich R, et al. Chronic thromboembolic and pulmonary arterial hypertension share acute vasoreactivity properties. Chest. 2006;130(3):841-6. Exclude - Does not include intervention of interest. [pmid: 16963684].
Ulrich S, Huber LC, Fischler M, et al. Platelet serotonin content and transpulmonary platelet serotonin gradient in patients with pulmonary hypertension. Respiration. 2011;81(3):211-216. Exclude - Does not include intervention of interest. [pmid: 20431284].
Ulrich S, Speich R, Domenighetti G, et al. Bosentan therapy for chronic thromboembolic pulmonary hypertension. A national open label study assessing the effect of Bosentan on haemodynamics, exercise capacity, quality of life, safety and tolerability in patients with chronic thromboembolic pulmonary hypertension (BOCTEPH-Study). Swiss Med Wkly. 2007;137(41–42):573-80. Exclude - No study population of interest. [pmid: 17990150].
Uner A, Dogan M, Demirtas M, et al. Comparison of nifedipine and captopril in children with pulmonary hypertension due to bronchopneumonia. J Trop Pediatr. 2008;54(5):294-9. Exclude - No study population of interest. [pmid: 18304952].
Upadhya B, Ntim W, Little W, et al. Identification of high risk patient with sickle cell disease using echocardiography. J Am Soc Echocardiogr. 2012;25(6):B6. Exclude - Not a full publication.
Uslu S, Kumtepe S, Bulbul A, et al. A comparison of magnesium sulphate and sildenafil in the treatment of the newborns with persistent pulmonary hypertension: a randomized controlled trial. J Trop Pediatr. 2011;57(4):245-50. Exclude - no primary or secondary outcomes of interest. [pmid: 20923790].
Vachiery JL, Delcroix M, Huez S, et al. Sildenafil use in pulmonary hypertension: The Belgian experience. Acta Cardiol. 2011;66(1):130-131. Exclude - Not a full publication.
Vachiery JL, Hill N, Zwicke D, et al. Transitioning from i.v. epoprostenol to subcutaneous treprostinil in pulmonary arterial hypertension. Chest. 2002;121(5):1561-5. Exclude - no primary or secondary outcomes of interest. [pmid: 12006444].
Vadapalli S, Rani HS, Sastry B, et al. Endothelin-1 and endothelial nitric oxide polymorphisms in idiopathic pulmonary arterial hypertension. Int J Mol Epidemiol Genet. 2010;1(3):208-13. Exclude - Does not include intervention of interest. [pmid: 21537392].
Valdivia-Arenas MA, Sood N. Micrococcus bloodstream infection in patients with pulmonary hypertension on epoprostenol. Infect Dis Clin Pract. 2008;16(5):285-287. Exclude - No comparisons of interest.
Valerio CJ, Handler CE, Kabunga P, et al. Clinical experience with bosentan and sitaxentan in connective tissue disease-associated pulmonary arterial hypertension. Rheumatology (Oxford). 2010;49(11):2147-53. Exclude - No comparisons of interest. [pmid: 20675359].
Valerio G, Bracciale P, Grazia D’Agostino A. Effect of bosentan upon pulmonary hypertension in chronic obstructive pulmonary disease. Ther Adv Respir Dis. 2009;3(1):15-21. Exclude - No study population of interest. [pmid: 19293199].
van Beers EJ, Nur E, Schaefer-Prokop CM, et al. Cardiopulmonary imaging, functional and laboratory studies in sickle cell disease associated pulmonary hypertension. Am J Hematol. 2008;83(11):850-4. Exclude - Does not include intervention of interest. [pmid: 18819095].
Van De Bruaene A, De Meester P, Voigt JU, et al. Right ventricular function in patients with Eisenmenger syndrome. Acta Cardiol. 2012;67(1):144-145. Exclude - Not a full publication.
van Loon RL, Hoendermis ES, Duffels MG, et al. Long-term effect of bosentan in adults versus children with pulmonary arterial hypertension associated with systemic-to-pulmonary shunt: does the beneficial effect persist?. Am Heart J. 2007;154(4):776-82. Exclude - No comparisons of interest. [pmid: 17893008].
van Loon RL, Roofthooft MT, Delhaas T, et al. Outcome of pediatric patients with pulmonary arterial hypertension in the era of new medical therapies. Am J Cardiol. 2010;106(1):117-24. Exclude - Does not include intervention of interest. [pmid: 20609658].
Van Riel ACMJ, Schuuring M, Vis J, et al. Determinants of mortality in adults with pulmonary arterial hypertension due to congenital heart disease after initiation of advanced therapy. J Am Coll Cardiol. 2012;59(13):E1595. Exclude - Not a full publication.
Varga J. Endothelin-I receptor antagonist for the treatment of pulmonary arterial hypertension in systemic sclerosis. Curr Rheumatol Rep. 2003;5(2):145-6. Exclude - Not a full publication. [pmid: 12628045].
Vargas-Origel A, Gomez-Rodriguez G, Aldana-Valenzuela C, et al. The use of sildenafil in persistent pulmonary hypertension of the newborn. Am J Perinatol. 2010;27(3):225-30. Exclude - no primary or secondary outcomes of interest. [pmid: 19866403].
Vassallo FG, Kodric M, Scarduelli C, et al. Bosentan for patients with chronic thromboembolic pulmonary hypertension. Eur J Intern Med. 2009;20(1):24-9. Exclude - No study population of interest. [pmid: 19237088].
Vassalos A, Peng E, Young D, et al. Pre-operative sildenafil and pulmonary endothelial-related complications following cardiopulmonary bypass: a randomised trial in children undergoing cardiac surgery. Anaesthesia. 2011;66(6):472-80. Exclude - Does not include intervention of interest. [pmid: 21457152].
Vegh J, Szodoray P, Kappelmayer J, et al. Clinical and immunoserological characteristics of mixed connective tissue disease associated with pulmonary arterial hypertension. Scand J Immunol. 2006;64(1):69-76. Exclude - Does not include intervention of interest. [pmid: 16784493].
Vida VL, Gaitan G, Quezada E, et al. Low-dose oral sildenafil for patients with pulmonary hypertension: a cost-effective solution in countries with limited resources. Cardiol Young. 2007;17(1):72-7. Exclude - no primary or secondary outcomes of interest. [pmid: 17184573].
Vijay P, Szekely L, Sharp TG, et al. Adrenomedullin in patients at high risk for pulmonary hypertension. Ann Thorac Surg. 1998;66(2):500-5. Exclude - Does not include intervention of interest. [pmid: 9725392].
Vijlbrief DC, Benders MJ, Kemperman H, et al. B-Type Natriuretic Peptide and Rebound during Treatment for Persistent Pulmonary Hypertension. J Pediatr. 2012;160(1):111-115. e1. Exclude - no primary or secondary outcomes of interest. [pmid: 21839472].
Villalba WO, Sampaio-Barros PD, Pereira MC, et al. Six-minute walk test for the evaluation of pulmonary disease severity in scleroderma patients. Chest. 2007;131(1):217-22. Exclude - no primary or secondary outcomes of interest. [pmid: 17218579].
Villegas FA, Sanchez TS, Palenciano CG. Diagnostic techniques of pulmonary hypertension in candidates for liver transplant. Gastroenterol Hepatol Continuada. 2007;6(5):237-241. Exclude - Not available in English.
Vis JC, Duffels MG, Mulder P, et al. Prolonged beneficial effect of bosentan treatment and 4-year survival rates in adult patients with pulmonary arterial hypertension associated with congenital heart disease. Int J Cardiol. 2011. Exclude - No comparisons of interest. [pmid: 21723630].
Vizza CD, Badagliacca R, Poscia R, et al. Prognostic factors in severe pulmonary hypertension patients who need parenteral prostanoid therapy: The impact of late referral. Chest. 2011;140(4). Exclude - Not a full publication.
Vizza CD, Badagliacca R, Sciomer S, et al. Mid-term efficacy of beraprost, an oral prostacyclin analog, in the treatment of distal CTEPH: a case control study. Cardiology. 2006;106(3):168-73. 16645271. Exclude - No study population of interest. [pmid: 16645271].
Vizza CD, Rocca GD, Roma AD, et al. Acute hemodynamic effects of inhaled nitric oxide, dobutamine and a combination of the two in patients with mild to moderate secondary pulmonary hypertension. Crit Care. 2001;5(6):355-61. Exclude - No study population of interest. [pmid: 11737925].
Vizza CD, Sciomer S, Morelli S, et al. Long term treatment of pulmonary arterial hypertension with beraprost, an oral prostacyclin analogue. Heart. 2001;86(6):661-5. Exclude - No comparisons of interest. [pmid: 11711462].
Vogel-Claussen J, Skrok J, Shehata ML, et al. Right and left ventricular myocardial perfusion reserves correlate with right ventricular function and pulmonary hemodynamics in patients with pulmonary arterial hypertension. Radiology. 2011;258(1):119-27. Exclude - Does not include intervention of interest. [pmid: 20971775].
von Haehling S, von Bardeleben RS, Kramm T, et al. Inflammation in right ventricular dysfunction due to thromboembolic pulmonary hypertension. Int J Cardiol. 2010;144(2):206-11. Exclude - No study population of interest. [pmid: 19411119].
Voskaridou E, Tsetsos G, Tsoutsias A, et al. Pulmonary hypertension in patients with sickle cell/beta thalassemia: incidence and correlation with serum N-terminal pro-brain natriuretic peptide concentrations. Haematologica. 2007;92(6):738-43. Exclude - No comparisons of interest. [pmid: 17550845].
Voswinckel R, Enke B, Reichenberger F, et al. Favorable effects of inhaled treprostinil in severe pulmonary hypertension: results from randomized controlled pilot studies. J Am Coll Cardiol. 2006;48(8):1672-81. Exclude - No comparisons of interest. [pmid: 17045906].
Voswinckel R, Reichenberger F, Enke B, et al. Acute effects of the combination of sildenafil and inhaled treprostinil on haemodynamics and gas exchange in pulmonary hypertension. Pulm Pharmacol Ther. 2008;21(5):824-32. Exclude - no primary or secondary outcomes of interest. [pmid: 18657627].
Voswinckel R, Reichenberger F, Gall H, et al. Metered dose inhaler delivery of treprostinil for the treatment of pulmonary hypertension. Pulm Pharmacol Ther. 2009;22(1):50-6. Exclude - no primary or secondary outcomes of interest. [pmid: 19071225].
Wahl A, Praz F, Schwerzmann M, et al. Assessment of right ventricular systolic function: Comparison between cardiac magnetic resonance derived ejection fraction and pulsed-wave tissue Doppler imaging of the tricuspid annulus. Int J Cardiol. 2011;151(1):58-62. Exclude - no primary or secondary outcomes of interest. [pmid: 20537415].
Walkey AJ, Fein D, Horbowicz KJ, et al. Differential response to intravenous prostacyclin analog therapy in patients with pulmonary arterial hypertension. Pulm Pharmacol Ther. 2011;24(4):421-5. Exclude - no primary or secondary outcomes of interest. [pmid: 21251994].
Wang T, Li SX, Zhang XQ, et al. Study on the effect of adrenomedulin and urotensin-II on pulmonary hypertension of patients with congenital heart disease. Nat Med J China. 2005;85(38):2691-2695. Exclude - Not available in English.
Wang X, Mendelsohn L, Alien D, et al. Levels of placental growth factor and endothelin-1 in adults with sickle cell disease are linked to markers of hemolysis, inflammation, iron overload and pulmonary hypertension. Am J Hematol. 2010;85(8):E19. Exclude - Not a full publication.
Warrell C, Dobarro D, Handler C, et al. Predictors of bosentan monotherapy discontinuation in SSc-pah patients. Rheumatology (Oxford). 2012;51:ii49-ii50. Exclude - Not a full publication.
Warwick G, Thomas PS, Yates DH. Biomarkers in pulmonary hypertension. Eur Respir J. 2008;32(2):503-12. Exclude - Background Other. [pmid: 18669790].
Wasielewski S. Phosphodiesterase 5 inhibitor: Sildenafil lowers pulmonary hypertension. Dtsch Apoth Ztg. 2003;143(1–2):46-48. Exclude - Not available in English.
Watanabe H. A potential role of sildenafil, a selective PDE-5 inhibitor, in the management of pulmonary hypertension. Respir Circ. 2003;51(9):881-886. Exclude - Not available in English.
Wax D, Garofano R, Barst RJ. Effects of long-term infusion of prostacyclin on exercise performance in patients with primary pulmonary hypertension. Chest. 1999;116(4):914-20. Exclude - No comparisons of interest. [pmid: 10531153].
Wensel R, Opitz CF, Ewert R, et al. Effects of iloprost inhalation on exercise capacity and ventilatory efficiency in patients with primary pulmonary hypertension. Circulation. 2000;101(20):2388-92. Exclude - no primary or secondary outcomes of interest. [pmid: 10821815].
Widimsky J. Calcium antagonists in the vasodilatory treatment of primary pulmonary hypertension. Cor Vasa. 1990;32(2 Suppl):73-80. Exclude – not a full publication. [pmid: 2143462].
Wiedemann R, Ghofrani HA, Weissmann N, et al. Atrial natriuretic peptide in severe primary and nonprimary pulmonary hypertension: response to iloprost inhalation. J Am Coll Cardiol. 2001;38(4):1130-6. Exclude - no primary or secondary outcomes of interest. [pmid: 11583893].
Wierzbicki K, Przybylowski P, Sobczyk D, et al. Markers of pulmonary hypertension in potential candidates to heart transplantation. Przegl Lek. 2006;63(12):1263-8. Exclude - No study population of interest. [pmid: 17642136].
Wierzbicki K, Sobczyk D, Bochenek M, et al. Analysis of correlations between N-terminal pro-B-type natriuretic peptide levels and markers of venous pulmonary hypertension in patients referred for heart transplantation. Pol Arch Med Wewn. 2012;122(6):291-297. Exclude - No study population of interest. [pmid: 22660685].
Wilkens H, Bauer M, Forestier N, et al. Influence of inhaled iloprost on transpulmonary gradient of big endothelin in patients with pulmonary hypertension. Circulation. 2003;107(11):1509-13. Exclude - no primary or secondary outcomes of interest. [pmid: 12654608].
Wilkens H, Guth A, Konig J, et al. Effect of inhaled iloprost plus oral sildenafil in patients with primary pulmonary hypertension. Circulation. 2001;104(11):1218-22. Exclude - no primary or secondary outcomes of interest. [pmid: 11551870].
Williams MH, Das C, Handler CE, et al. Systemic sclerosis associated pulmonary hypertension: improved survival in the current era. Heart. 2006;92(7):926-32. Exclude - Does not include intervention of interest. [pmid: 16339813].
Williamson DJ, Wallman LL, Jones R, et al. Hemodynamic effects of Bosentan, an endothelin receptor antagonist, in patients with pulmonary hypertension. Circulation. 2000;102(4):411-8. Exclude - no primary or secondary outcomes of interest. [pmid: 10908213].
Winslow TM, Ossipov MA, Fazio GP, et al. Five-year follow-up study of the prevalence and progression of pulmonary hypertension in systemic lupus erythematosus. Am Heart J. 1995;129(3):510-5. Exclude - no primary or secondary outcomes of interest. [pmid: 7872181].
Winterhalter M, Simon A, Fischer S, et al. Comparison of inhaled iloprost and nitric oxide in patients with pulmonary hypertension during weaning from cardiopulmonary bypass in cardiac surgery: a prospective randomized trial. J Cardiothorac Vasc Anesth. 2008;22(3):406-13. Exclude - no primary or secondary outcomes of interest. [pmid: 18503929].
Wolff B, Lodziewski S, Bollmann T, et al. Impaired peripheral endothelial function in severe idiopathic pulmonary hypertension correlates with the pulmonary vascular response to inhaled iloprost. Am Heart J. 2007;153(6):1088 e1-7. Exclude - Does not include intervention of interest. [pmid: 17540215].
Wong HA, Yan S, McGlothlin DP, et al. Comparative effectiveness of endothelin receptor antagonists for the treatment of pulmonary arterial hypertension (a pilot study). Pharmacotherapy. 2011;31(10):321e. Exclude - Not a full publication.
Wong RC, Koh GM, Choong PH, et al. Oral sildenafil therapy improves health-related quality of life and functional status in pulmonary arterial hypertension. Int J Cardiol. 2007;119(3):400-2. Exclude - No comparisons of interest. [pmid: 17064789].
Woodmansey PA, O’Toole L, Channer KS, et al. Acute pulmonary vasodilatory properties of amlodipine in humans with pulmonary hypertension. Heart. 1996;75(2):171-3. Exclude - No study population of interest. [pmid: 8673756].
Wylie BJ, Epps KC, Gaddipati S, et al. Correlation of transthoracic echocardiography and right heart catheterization in pregnancy. J Perinat Med. 2007;35(6):497-502. Exclude - No study population of interest. [pmid: 18052837].
Xiong CM, Lu XL, Shan GL, et al. Oral Sildenafil Therapy for Chinese Patients With Pulmonary Arterial Hypertension: A Multicenter Study. J Clin Pharmacol. 2011. Exclude - No comparisons of interest. [pmid: 21415281].
Xiong CM, Lu XL, Shan GL, et al. Oral sildenafil therapy for Chinese patients with pulmonary arterial hypertension: a multicenter study. J Clin Pharmacol. 2012;52(3):425-31. Exclude - No comparisons of interest. [pmid: 21415281].
Xu XQ, Jing ZC, Zhang JH, et al. The efficacy and safety of sildenafil in Chinese patients with pulmonary arterial hypertension. Hypertens Res. 2009;32(10):911-5. Exclude - No comparisons of interest. [pmid: 19644505].
Yadav R, Anandaraja S, Bhargava B, et al. Acute hemodynamic effects of nicorandil in patients with primary pulmonary arterial hypertension. Indian Heart J. 2005;57(6):666-9. Exclude - Does not include intervention of interest. [pmid: 16521635].
Yamakawa H, Shiomi T, Sasanabe R, et al. Pulmonary hypertension in patients with severe obstructive sleep apnea. Psychiatry Clin Neurosci. 2002;56(3):311-2. Exclude - No study population of interest. [pmid: 12047610].
Yamane K, Ihn H, Asano Y, et al. Clinical and laboratory features of scleroderma patients with pulmonary hypertension. Rheumatology (Oxford). 2000;39(11):1269-71. Exclude - Does not include intervention of interest. [pmid: 11085808].
Yeager ME, Colvin KL, Everett AD, et al. Plasma proteomics of differential outcome to long-term therapy in children with idiopathic pulmonary arterial hypertension. Proteomics - Clinical Applications. 2012;6(5–6):257-267. Exclude - Does not include intervention of interest. [pmid: 22653875].
Yeo TC, Dujardin KS, Tei C, et al. Value of a Doppler-derived index combining systolic and diastolic time intervals in predicting outcome in primary pulmonary hypertension. Am J Cardiol. 1998;81(9):1157-61. Exclude - Does not include intervention of interest. [pmid: 9605059].
Yigla M, Azzam Z, Rinkevich D, et al. Unexplained pulmonary hypertension in older patients: Clinical characteristics, follow-up, and prognosis. J Cardiovasc Diagn Proc. 1997;14(1):9-15. Exclude - No comparisons of interest.
Yilmaz N, Olgun S, Ahiskali R, et al. Serum and sputum caveolin-1, TGF-(beta) and et-1 levels in scleroderma patients. Rheumatology (Oxford). 2012;51:ii27. Exclude - Not a full publication.
Yinguang S, Lijiang T, Qinhua Z, et al. Assessment of right heart function in the patients with pulmonary arterial hypertension using 2D strain echocardiography. Heart. 2011;97:A197. Exclude - Not a full publication.
Yoshida S, Shirato K, Shimamura R, et al. Efficacy, safety, and pharmacokinetics of ambrisentan in Japanese adults with pulmonary arterial hypertension. Curr Med Res Opin. 2011;27(9):1827-34. Exclude - No comparisons of interest. [pmid: 21812736].
You XD, Pu ZX, Peng XJ, et al. Tissue Doppler imaging study of right ventricular myocardial systolic activation in subjects with pulmonary arterial hypertension. Chin Med J (Engl). 2007;120(13):1172-5. Exclude - no primary or secondary outcomes of interest. [pmid: 17637247].
Yung D, Widlitz AC, Rosenzweig EB, et al. Outcomes in children with idiopathic pulmonary arterial hypertension. Circulation. 2004;110(6):660-5. Exclude - No comparisons of interest. [pmid: 15289375].
Zafrir B, Shehadeh W, Salman N, et al. Prognostic factors in pulmonary hypertension: The obesity paradox. J Am Coll Cardiol. 2012;59(13):E1592. Exclude - Not a full publication.
Zhang DZ, Zhu XY, Meng J, et al. Acute hemodynamic responses to adenosine and iloprost in patients with congenital heart defects and severe pulmonary arterial hypertension. Int J Cardiol. 2011;147(3):433-7. Exclude - Does not include intervention of interest. [pmid: 20537740].
Zhang J, Zhang Y, Li N, et al. Potential diagnostic biomarkers in serum of idiopathic pulmonary arterial hypertension. Respir Med. 2009;103(12):1801-6. Exclude - Does not include intervention of interest. [pmid: 19703762].
Zhang R, Dai LZ, Xie WP, et al. Survival of Chinese patients with pulmonary arterial hypertension in the modern treatment era. Chest. 2011;140(2):301-9. Exclude - No comparisons of interest. [pmid: 21330386].
Zhang ZN, Jiang X, Zhang R, et al. Oral sildenafil treatment for Eisenmenger syndrome: A prospective, open-label, multicentre study. Heart. 2011;97(22):1876-1881. Exclude - No comparisons of interest. [pmid: 21948962].
Zhu H, Wang GY, Xue H. Therapeutic effect of ambrisentan on congenital heart disease associated with PAH. Am J Cardiol. 2012;109(7):136S. Exclude - Not a full publication.
Ziegler JW, Ivy DD, Wiggins JW, et al. Effects of dipyridamole and inhaled nitric oxide in pediatric patients with pulmonary hypertension. Am J Respir Crit Care Med. 1998;158(5 Pt 1):1388-95. Exclude - Does not include intervention of interest. [pmid: 9817684].
Zimbarra Cabrita I, Ruisanchez C, Dawson D, et al. Right ventricular function in patients with pulmonary hypertension; the value of myocardial performance index measured by tissue Doppler imaging. Eur J Echocardiogr. 2010;11(8):719-24. Exclude - no primary or secondary outcomes of interest. [pmid: 20410189].
Zompatori M, Battaglia M, Rimondi MR, et al. Hemodynamic estimation of chronic cor pulmonale by Doppler echocardiography. Clinical value and comparison with other noninvasive imaging techniques. Rays. 1997;22(1):73-93. Exclude - Not available in English. [pmid: 9145016].
Zuo XR, Zhang R, Jiang X, et al. Usefulness of intravenous adenosine in idiopathic pulmonary arterial hypertension as a screening agent for identifying long-term responders to calcium channel blockers. Am J Cardiol. 2012;109(12):1801-1806. Exclude - No comparisons of interest. [pmid: 22459309].