# Exact Search Strings

## PubMed^®^ search strategy (August 14, 2012)

Table A-1 PubMed search terms for KQ 1: Screening for PAH

Set # | Terms
#1 | (“Hypertension, Pulmonary”[Mesh] OR “Idiopathic pulmonary hypertension “[Supplementary Concept]) OR (“pulmonary hypertension”[ti] OR “pulmonary arterial hypertension”[ti] OR “pulmonary artery hypertension”[ti]) OR ((“hypertension, pulmonary”[MeSH Terms] OR “pulmonary hypertension”[tiab] OR (“pulmonary”[tiab] AND “hypertension”[tiab])) AND (pah[ti] OR ipah[ti] OR pph[ti]))
#2 | “Echocardiography”[Mesh] OR echocardiogram[tiab] OR echocardiography[tiab] OR TTE[tiab] OR TEE[tiab] OR echo[tiab]
#3 | (sensitive[tiab] OR sensitivity[tiab] OR specificity[tiab] OR “sensitivity and specificity”[MeSH Terms] OR diagnosis[tiab] OR diagnostic[tiab] OR diagnosed[tiab] OR “diagnosis”[MeSH Terms] OR “diagnosis”[Subheading] OR screening[tiab] OR screen[tiab] OR “mass screening”[MeSH Terms] OR “cross-sectional studies”[MeSH Terms] OR cross-sectional[tiab]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp]) NOT (“animals”[MeSH Terms] NOT “humans”[MeSH Terms])
#4 | #1 AND #2 AND #3 English, Publication Date from 1995 to 2011
#5 | “Natriuretic Peptides”[Mesh] OR “Uric Acid”[Mesh] OR “Troponin”[Mesh] OR “Nitric Oxide”[Mesh] OR “dimethylarginine”[Supplementary Concept] OR “fibrin fragment D”[Supplementary Concept] OR “Serotonin”[Mesh] OR “von Willebrand Factor”[Mesh] OR “Thrombomodulin”[Mesh] OR “Selectins”[Mesh] OR “C-Reactive Protein”[Mesh] OR “Isoprostanes”[Mesh] OR “Interleukins”[Mesh] OR “Endothelin-1”[Mesh] OR “Cyclic GMP”[Mesh] OR (Natriuretic[tiab] AND Peptides[tiab]) OR (Natriuretic[tiab] AND Peptide[tiab]) OR “Uric Acid”[tiab] OR “Troponin”[tiab] OR “Nitric Oxide”[tiab] OR “dimethylarginine”[tiab] OR “d-dimer”[tiab] OR “Serotonin”[tiab] OR “Willebrand Factor”[tiab] OR “Thrombomodulin”[tiab] OR “Selectins”[tiab] OR “Selectin”[tiab] AND R[All Fields] AND “C-Reactive Protein”[tiab] OR “Isoprostanes”[tiab] OR Isoprostane[tiab] OR “Interleukins”[tiab] OR “Interleukin”[tiab] OR “Endothelin-1”[tiab] OR “Cyclic GMP”[tiab] OR cgmp[tiab] OR (soluble[tiab] AND ligand[tiab]) OR (endothelial[tiab] AND dysfunction[tiab]) OR “Biological Markers”[Mesh] OR (biological[tiab] AND (marker[tiab] OR markers[tiab])) OR biomarker[tiab] OR biomarkers[tiab]
#6 | #1 AND #5 AND #3 English, Publication Date from 1995 to 2011
#7 | #1 AND #2 AND #5 English, Publication Date from 1995 to 2011

Table A-2 PubMed search terms for KQ 2: Management of PAH

Set # | Terms
#1 | (“Hypertension, Pulmonary”[Mesh] OR “Idiopathic pulmonary hypertension “[Supplementary Concept]) OR (“pulmonary hypertension”[ti] OR “pulmonary arterial hypertension”[ti] OR “pulmonary artery hypertension”[ti]) OR ((“hypertension, pulmonary”[MeSH Terms] OR “pulmonary hypertension”[tiab] OR (“pulmonary”[tiab] AND “hypertension”[tiab])) AND (pah[ti] OR ipah[ti] OR pph[ti]))
#2 | “Echocardiography”[Mesh] OR echocardiogram[tiab] OR echocardiography[tiab] OR TTE[tiab] OR TEE[tiab] OR echo[tiab]
#3 | #1 AND #2 English, Publication Date from 1995 to 2011
#4 | (clinical[tiab] AND decision[tiab]) OR (clinical[tiab] AND decisions[tiab]) OR (decision[tiab] AND making[tiab]) OR screening[tiab] OR screen[tiab] OR “mass screening”[MeSH Terms] OR management[tiab] OR “treatment outcome”[MeSH Terms] OR outcome[tiab] OR outcomes[tiab] OR “Patient Care Management”[Mesh] OR treatment[tiab] OR therapy[tiab]
#5 | #3 AND #4 English, Publication Date from 1995 to 2011
#6 | “Natriuretic Peptides”[Mesh] OR “Uric Acid”[Mesh] OR “Troponin”[Mesh] OR “Nitric Oxide”[Mesh] OR “dimethylarginine”[Supplementary Concept] OR “fibrin fragment D”[Supplementary Concept] OR “Serotonin”[Mesh] OR “von Willebrand Factor”[Mesh] OR “Thrombomodulin”[Mesh] OR “Selectins”[Mesh] OR “C-Reactive Protein”[Mesh] OR “Isoprostanes”[Mesh] OR “Interleukins”[Mesh] OR “Endothelin-1”[Mesh] OR “Cyclic GMP”[Mesh] OR (Natriuretic[tiab] AND Peptides[tiab]) OR (Natriuretic[tiab] AND Peptide[tiab]) OR “Uric Acid”[tiab] OR “Troponin”[tiab] OR “Nitric Oxide”[tiab] OR “dimethylarginine”[tiab] OR “d-dimer”[tiab] OR “Serotonin”[tiab] OR “Willebrand Factor”[tiab] OR “Thrombomodulin”[tiab] OR “Selectins”[tiab] OR “Selectin”[tiab] AND R[All Fields] AND “C-Reactive Protein”[tiab] OR “Isoprostanes”[tiab] OR Isoprostane[tiab] OR “Interleukins”[tiab] OR “Interleukin”[tiab] OR “Endothelin-1”[tiab] OR “Cyclic GMP”[tiab] OR cgmp[tiab] OR (soluble[tiab] AND ligand[tiab]) OR (endothelial[tiab] AND dysfunction[tiab]) OR “Biological Markers”[Mesh] OR (biological[tiab] AND (marker[tiab] OR markers[tiab])) OR biomarker[tiab] OR biomarkers[tiab]
#7 | #1 AND #6 English, Publication Date from 1995 to 2011
#8 | #7 AND #4 English, Publication Date from 1995 to 2011
#9 | #1 AND #2 AND #6 English, Publication Date from 1995 to 2011
#10 | #1 AND (#2 OR #6) English, Publication Date from 1995 to 2011
#11 | (sensitive[tiab] OR sensitivity[tiab] OR specificity[tiab] OR “sensitivity and specificity”[MeSH Terms] OR diagnosis[tiab] OR diagnostic[tiab] OR diagnosed[tiab] OR “diagnosis”[MeSH Terms] OR “diagnosis”[Subheading] OR screening[tiab] OR screen[tiab] OR “mass screening”[MeSH Terms] OR “cross-sectional studies”[MeSH Terms] OR cross-sectional[tiab]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp]) NOT (“animals”[MeSH Terms] NOT “humans”[MeSH Terms])
#12 | #1 AND (#2 OR #6) AND (#3 OR #11) English, Publication Date from 1995 to 2011

Table A-3 PubMed search terms for KQ 3: Monotherapy vs. Combination Therapy for PAH

Set # | Terms
#1 | (“Hypertension, Pulmonary”[Mesh] OR “Idiopathic pulmonary hypertension “[Supplementary Concept]) OR (“pulmonary hypertension”[ti] OR “pulmonary arterial hypertension”[ti] OR “pulmonary artery hypertension”[ti]) OR ((“hypertension, pulmonary”[MeSH Terms] OR “pulmonary hypertension”[tiab] OR (“pulmonary”[tiab] AND “hypertension”[tiab])) AND (pah[ti] OR ipah[ti] OR pph[ti]))
#2 | (“Calcium Channel Blockers”[Mesh] OR “Calcium Channel Blockers”[Pharmacological Action] OR calcium channel blockers[tiab] OR calcium channel blocker[tiab] OR nifedipine[tiab] OR diltiazem[tiab] OR amlodipine[tiab]) OR (“prostaglandins”[MeSH Terms] OR “prostaglandins”[tiab] OR “prostaglandins”[tiab] OR “prostanoid”[tiab] OR “prostanoids”[tiab] OR “epoprostenol”[MeSH Terms] OR “epoprostenol”[tiab] OR “prostacyclin”[tiab] OR “treprostinil”[Supplementary Concept] OR “treprostinil”[tiab] OR “iloprost”[MeSH Terms] OR “iloprost”[tiab] OR “Receptors, Endothelin/antagonists and inhibitors”[Mesh] OR ((“endothelins”[MeSH Terms] OR “endothelins”[tiab] OR “endothelin”[tiab]) AND (antagonist[tiab] OR “antagonists”[tiab] OR “inhibitors”[tiab])) OR “bosentan”[Supplementary Concept] OR “bosentan”[tiab] OR “ambrisentan”[Supplementary Concept] OR “ambrisentan”[tiab] OR “phosphodiesterase inhibitors”[MeSH Terms] OR (“phosphodiesterase”[tiab] AND “inhibitors”[tiab]) OR “phosphodiesterase inhibitors”[tiab] OR “phosphodiesterase inhibitors”[Pharmacological Action] OR “phosphodiesterase 5 inhibitors”[tiab] OR “phosphoric diester hydrolases”[MeSH Terms] OR (“phosphoric”[tiab] AND “diester”[tiab] AND “hydrolases”[tiab]) OR ((“phosphodiesterase”[tiab] OR “phosphodiesterases”[tiab]) AND (inhibitor[tiab] OR “antagonists and inhibitors”[Subheading] OR “antagonists”[tiab] OR “inhibitors”[tiab] OR antagonist[tiab])) OR (pde5[tiab] AND (inhibitor[tiab] OR “antagonists and inhibitors”[Subheading] OR “antagonists”[tiab] OR “antagonist”[tiab] OR “inhibitors”[tiab] OR “inhibitors”[tiab])) OR pde5i[tiab] OR “sildenafil”[Supplementary Concept] OR “sildenafil”[tiab] OR “tadalafil”[Supplementary Concept] OR “tadalafil”[tiab] OR “Vasodilator Agents”[Mesh:noexp] OR “Vasodilator Agents “[Pharmacological Action])
#3 | (randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR “drug therapy”[Subheading] OR randomly[tiab] OR trial[tiab] OR groups[tiab] OR Clinical trial[pt] OR “clinical trial”[tw] OR “clinical trials”[tw] OR “evaluation studies”[Publication Type] OR “evaluation studies as topic”[MeSH Terms] OR “evaluation study”[tw] OR evaluation studies[tw] OR “intervention studies”[MeSH Terms] OR “intervention study”[tw] OR “intervention studies”[tw] OR “case-control studies”[MeSH Terms] OR “case-control”[tw] OR “cohort studies”[MeSH Terms] OR cohort[tw] OR “longitudinal studies”[MeSH Terms] OR “longitudinal”[tw] OR longitudinally[tw] OR “prospective”[tw] OR prospectively[tw] OR “retrospective studies”[MeSH Terms] OR “retrospective”[tw] OR “follow up”[tw] OR “comparative study”[Publication Type] OR “comparative study”[tw] OR systematic[subset] OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[tw] OR “meta-analyses”[tw]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp]) NOT (“animals”[MeSH Terms] NOT “humans”[MeSH Terms])
#4 | #1 AND #2 AND #3 English, Publication Date from 1995 to 2011

## Embase^®^ search strategy (August 14, 2012)

Platform: Embase.com

Table A-4 Embase search terms for KQ 1: Screening for PAH

Set # | Terms
#1 | ‘pulmonary hypertension’/exp OR “idiopathic pulmonary hypertension”:ab,ti OR “pulmonary arterial hypertension”:ab,ti OR “pulmonary artery hypertension”:ab,ti OR “pulmonary hypertension”:ab,ti OR pah:ab,ti OR ipah:ab,ti OR pph:ab,ti
#2 | ‘echocardiography’/exp OR echocardiography:ab,ti OR echocardiogram:ab,ti OR echo:ab,ti OR TEE:ab,ti OR TEE:ab,ti
#3 | (‘sensitivity and specificity’/exp OR diagnosis:de OR diagnostic:de OR ‘screening’/exp OR ‘cross-sectional study’/exp OR sensitive:ab,ti OR sensitive:ab,ti OR sensitivity:ab,ti OR specificity:ab,ti OR diagnosis:ab,ti OR diagnostic:ab,ti OR diagnosed:ab,ti OR screening:ab,ti OR screen:ab,ti OR cross-sectional:ab,ti OR likelihood:ab,ti ) NOT ‘editorial’/exp OR ‘letter’/exp OR ‘case report’/exp
#4 | #1 AND #2 AND #3
#5 | #1 AND #2 AND #3 AND [embase]/lim NOT [medline]/lim AND [humans]/lim AND [1995–2012]/py
#6 | ‘natriuretic factor’/exp OR ‘uric acid’/exp OR ‘troponin’/exp OR ‘nitric oxide’/exp OR ‘6 n,n’ dimethylarginine’/exp OR ‘serotonin’/exp OR ‘von Willebrand factor’/exp OR ‘C reactive protein’/exp OR ‘isoprostane derivative’/exp OR ‘interleukin derivative’/exp OR ‘endothelin 1’/exp OR ‘cyclic GMP’/exp OR ‘thrombomodulin’/exp OR ‘selectin’/exp OR ‘biological marker’/exp OR “Natriuretic Peptides”:ab,ti OR “Natriuretic Peptide”:ab,ti OR “Uric Acid”:ab,ti OR Troponin:ab,ti OR “Nitric Oxide”:ab,ti OR dimethylarginine:ab,ti OR d-dimer:ab,ti OR Serotonin:ab,ti OR “Willebrand Factor”:ab,ti OR Thrombomodulin:ab,ti OR Selectins:ab,ti OR Selectin:ab,ti OR “C-Reactive Protein”:ab,ti OR Isoprostanes:ab,ti OR Isoprostane:ab,ti OR Interleukins:ab,ti OR Interleukin:ab,ti OR Endothelin-1:ab,ti OR “Cyclic GMP”:ab,ti OR cgmp:ab,ti OR “soluble ligand”:ab,ti OR “biological marker”:ab,ti OR “biological markers”:ab,ti OR biomarker:ab,ti OR biomarkers:ab,ti OR “endothelial dysfunction”:ab,ti OR fibrin fragment:de
#7 | #1 AND #6 AND #3
#8 | #7 AND [embase]/lim NOT [medline]/lim AND [humans]/lim AND [1995–2012]/py
#9 | #1 AND #2 AND #3 AND #6 AND [embase]/lim NOT [medline]/lim AND [humans]/lim AND [1995–2012]/py

Table A-5 Embase search terms for KQ 2: Management of PAH

Set # | Terms
#1 | ‘pulmonary hypertension’/exp OR “idiopathic pulmonary hypertension”:ab,ti OR “pulmonary arterial hypertension”:ab,ti OR “pulmonary artery hypertension”:ab,ti OR “pulmonary hypertension”:ab,ti OR pah:ab,ti OR ipah:ab,ti OR pph:ab,ti
#2 | ‘echocardiography’/exp OR echocardiography:ab,ti OR echocardiogram:ab,ti OR echo:ab,ti OR TEE:ab,ti OR TEE:ab,ti
#3 | ‘treatment outcome’/exp OR ‘clinical decision making’/exp OR ‘decision making’/exp OR ‘patient care’/de OR (clinical:ab,ti AND decision:ab,ti) OR (clinical:ab,ti AND decisions:ab,ti) OR (decision:ab,ti AND making:ab,ti) OR management:ab,ti OR “treatment outcome”:ab,ti OR outcome:ab,ti OR outcomes:ab,ti OR treatment:ab,ti OR therapy:ab,ti OR ‘controlled clinical trial’/exp OR ‘clinical trial’/exp OR ‘evidence based medicine’/exp
#4 | #3 NOT (‘editorial’/exp OR ‘letter’/exp OR ‘case report’/exp)
#5 | #1 AND #2 AND #4
#6 | #5 AND [embase]/lim NOT [medline]/lim AND [humans]/lim AND [1995–2012]/py
#7 | ‘natriuretic factor’/exp OR ‘uric acid’/exp OR ‘troponin’/exp OR ‘nitric oxide’/exp OR ‘6 n,n’ dimethylarginine’/exp OR ‘serotonin’/exp OR ‘von Willebrand factor’/exp OR ‘C reactive protein’/exp OR ‘isoprostane derivative’/exp OR ‘interleukin derivative’/exp OR ‘endothelin 1’/exp OR ‘cyclic GMP’/exp OR ‘thrombomodulin’/exp OR ‘selectin’/exp OR ‘biological marker’/exp OR “Natriuretic Peptides”:ab,ti OR “Natriuretic Peptide”:ab,ti OR “Uric Acid”:ab,ti OR Troponin:ab,ti OR “Nitric Oxide”:ab,ti OR dimethylarginine:ab,ti OR d-dimer:ab,ti OR Serotonin:ab,ti OR “Willebrand Factor”:ab,ti OR Thrombomodulin:ab,ti OR Selectins:ab,ti OR Selectin:ab,ti OR “C-Reactive Protein”:ab,ti OR Isoprostanes:ab,ti OR Isoprostane:ab,ti OR Interleukins:ab,ti OR Interleukin:ab,ti OR Endothelin-1:ab,ti OR “Cyclic GMP”:ab,ti OR cgmp:ab,ti OR “soluble ligand”:ab,ti OR “biological marker”:ab,ti OR “biological markers”:ab,ti OR biomarker:ab,ti OR biomarkers:ab,ti OR “endothelial dysfunction”:ab,ti OR fibrin fragment:de
#8 | #1 AND #7 AND #4
#9 | #8 AND [embase]/lim NOT [medline]/lim AND [humans]/lim AND [1995–2012]/py
#10 | #1 AND #2 AND #7 AND [english]/lim AND [1995–2012]/py AND [embase]/lim NOT [medline]/lim AND [humans]/lim

Table A-6 Embase search terms for KQ 3: Monotherapy vs. Combination Therapy for PAH

Set # | Terms
#1 | ‘pulmonary hypertension’/exp OR “idiopathic pulmonary hypertension”:ab,ti OR “pulmonary arterial hypertension”:ab,ti OR “pulmonary artery hypertension”:ab,ti OR “pulmonary hypertension”:ab,ti OR pah:ab,ti OR ipah:ab,ti
#2 | ‘prostaglandin’/exp OR ‘iloprost’/exp OR ‘endothelin receptor’/exp OR ‘bosentan’/exp OR ‘ambrisentan’/exp OR ‘phosphodiesterase inhibitor’/exp OR ‘phosphodiesterase’/exp OR ‘sildenafil’/exp OR ‘tadalafil’/exp OR ‘vasodilator agent’/exp or “prostaglandin”:ab,ti OR “prostaglandins”:ab,ti OR “prostanoid”:ab,ti OR “prostanoids”:ab,ti OR “epoprostenol”:ab,ti OR “prostacyclin”:ab,ti OR “treprostinil”:ab,ti OR “iloprost”:ab,ti OR “bosentan”:ab,ti OR “ambrisentan”:ab,ti OR (“phosphodiesterase”:ab,ti AND “inhibitors”:ab,ti) OR “phosphodiesterase inhibitors”:ab,ti OR “phosphodiesterase 5 inhibitors”:ab,ti OR (“phosphoric”:ab,ti AND “diester”:ab,ti AND “hydrolases”:ab,ti) OR “sildenafil”:ab,ti OR “tadalafil”:ab,ti OR ((“phosphodiesterase”:ab,ti OR “phosphodiesterases”:ab,ti OR “endothelins”:ab,ti OR “endothelin”:ab,ti OR pde5:ab,ti) AND (inhibitor:ab,ti OR “antagonists”:ab,ti OR “inhibitors”:ab,ti OR antagonist:ab,ti))
#3 | ‘calcium channel blocking agent’/exp OR ‘calcium channel blocker’:ab,ti OR ‘calcium channel blockers’:ab,ti OR Amlodipine:ab,ti OR Amrinone:ab,ti OR anandamide:ab,ti OR anipamil:ab,ti OR azimilide:ab,ti OR Bencyclane:ab,ti OR benidipine:ab,ti OR Bepridil:ab,ti OR berbamine:ab,ti OR canadine:ab,ti OR ‘carboxyamido-triazole’:ab,ti OR caroverine:ab,ti OR cilnidipine:ab,ti OR Cinnarizine:ab,ti OR clentiazem:ab,ti OR Conotoxins:ab,ti OR darodipine:ab,ti OR dauricine:ab,ti OR devapamil:ab,ti OR Diltiazem:ab,ti OR dimeditiapramine:ab,ti OR dotarizine:ab,ti OR efonidipine:ab,ti OR emopamil:ab,ti OR enpiperate:ab,ti OR eperisone:ab,ti OR falipamil:ab,ti OR fantofarone:ab,ti OR fasudil:ab,ti OR Felodipine:ab,ti OR ‘fenamic acid’:ab,ti OR Fendiline:ab,ti OR Flunarizine:ab,ti OR fosfedil:ab,ti OR gabapentin:ab,ti OR Gallopamil:ab,ti OR Isradipine:ab,ti OR lacidipine:ab,ti OR lamotrigine:ab,ti OR lercanidipine:ab,ti OR Lidoflazine:ab,ti OR ‘Magnesium Sulfate’:ab,ti OR manidipine:ab,ti OR manoalide:ab,ti OR mepirodipine:ab,ti OR Mibefradil:ab,ti OR monatepil:ab,ti OR naftopidil:ab,ti OR Nicardipine:ab,ti OR Nifedipine:ab,ti OR niguldipine:ab,ti OR niludipin:ab,ti OR nilvadipine:ab,ti OR Nimodipine:ab,ti OR Nisoldipine:ab,ti OR Nitrendipine:ab,ti OR norverapamil:ab,ti OR ochratoxin:ab,ti OR octylonium:ab,ti OR ‘omega-Agatoxin’:ab,ti OR ‘omega-Conotoxin’:ab,ti OR ‘omega-Conotoxins’:ab,ti OR osthol:ab,ti OR oxodipine:ab,ti OR Perhexiline:ab,ti OR pinaverium:ab,ti OR piperidine:ab,ti OR pranidipine:ab,ti OR Prenylamine:ab,ti OR ‘ risedronic acid’:ab,ti OR ryodipine:ab,ti OR sesamodil:ab,ti OR stepholidine:ab,ti OR terodiline:ab,ti OR tetrahydropalmatine:ab,ti OR tetrandrine:ab,ti OR ‘tolfenamic acid’:ab,ti OR tranilast:ab,ti OR Verapamil:ab,ti OR ziconotide:ab,ti
#4 | (‘randomized controlled trial’/exp OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random*:ab,ti OR factorial*:ab,ti OR crossover*:ab,ti OR (cross NEAR/1 over*):ab,ti OR placebo*:ab,ti OR (doubl* NEAR/1 blind*):ab,ti OR (singl* NEAR/1 blind*):ab,ti OR assign*:ab,ti OR allocat*:ab,ti OR volunteer*:ab,ti OR ‘clinical study’/exp OR “clinical trial”:ti,ab OR “clinical trials”:ti,ab OR ‘controlled study’/exp OR ‘evaluation’/exp OR “evaluation study”:ab,ti OR “evaluation studies”:ab,ti OR “intervention study”:ab,ti OR “intervention studies”:ab,ti OR “case control”:ab,ti OR ‘cohort analysis’/exp OR cohort:ab,ti OR longitudinal*:ab,ti OR prospective:ab,ti OR prospectively:ab,ti OR retrospective:ab,ti OR ‘follow up’/exp OR “follow up”:ab,ti OR ‘comparative effectiveness’/exp OR ‘comparative study’/exp OR “comparative study”:ab,ti OR “comparative studies”:ab,ti OR ‘evidence based medicine’/exp OR “systematic review”:ab,ti OR “meta-analysis”:ab,ti OR “meta-analyses”:ab,ti) NOT (‘case report’/exp OR ‘case study’/exp OR ‘editorial’/exp OR ‘letter’/exp OR ‘note’/exp)
#5 | #1 AND (#2 OR #3) AND #4
#6 | #5 AND [embase]/lim NOT [medline]/lim AND [humans]/lim AND [1995–2012]/py

## Cochrane Database of Systematic Reviews (August 14, 2012)

Platform: Wiley

Table A-7 Cochrane search terms for KQs 1 and 2: Screening and Management of PAH

Set # | Terms
#1 | MeSH descriptor Hypertension, Pulmonary explode all trees OR (pulmonary hypertension):ti,ab,kw OR (idiopathic pulmonary hypertension):ti,ab,kw OR (pulmonary arterial hypertension):ti,ab,kw OR (pulmonary artery hypertension):ti,ab,kw OR pah:ti,ab,kw OR ipah:ti,ab,kw
#2 | MeSH descriptor echocardiography explode all trees OR echocardiography:ti,ab,kw OR echocardiogram:ti,ab,kw OR echo:ti,ab,kw OR TEE:ti,ab,kw OR TEE:ti,ab,kw
#3 | #1 AND #2 AND (Cochrane Reviews, other reviews) AND 1995–2012
#4 | MeSH descriptor Natriuretic Peptides explode all trees OR MeSH descriptor Uric Acid explode all trees OR MeSH descriptor Troponin explode all trees OR MeSH descriptor Nitric Oxide explode all trees OR MeSH descriptor Serotonin explode all trees OR MeSH descriptor von Willebrand Factor explode all trees OR MeSH descriptor C-Reactive Protein explode all trees OR MeSH descriptor Isoprostanes explode all trees OR MeSH descriptor Interleukins explode all trees OR MeSH descriptor Endothelins explode all trees OR MeSH descriptor Cyclic GMP explode all trees OR MeSH descriptor Thrombomodulin explode all trees OR MeSH descriptor Selectins explode all trees OR MeSH descriptor Biological Markers explode all trees OR (Natriuretic Peptides):ti,ab,kw OR (Natriuretic Peptide):ti,ab,kw OR (Uric Acid):ti,ab,kw OR Troponin:ti,ab,kw OR (Nitric Oxide):ti,ab,kw OR dimethylarginine:ti,ab,kw OR (d-dimer):ti,ab,kw OR Serotonin:ti,ab,kw OR (Willebrand Factor):ti,ab,kw OR Thrombomodulin:ti,ab,kw OR Selectins:ti,ab,kw OR Selectin:ti,ab,kw OR (C-Reactive Protein):ti,ab,kw OR Isoprostanes:ti,ab,kw OR Isoprostane:ti,ab,kw OR Interleukins:ti,ab,kw OR Interleukin:ti,ab,kw OR (Endothelin-1):ti,ab,kw OR (Cyclic GMP):ti,ab,kw OR cgmp:ti,ab,kw OR (soluble ligand):ti,ab,kw OR (biological marker):ti,ab,kw OR (biological markers):ti,ab,kw OR biomarker:ti,ab,kw OR biomarkers:ti,ab,kw OR (endothelial dysfunction):ti,ab,kw OR (fibrin fragment):ti,ab,kw
#5 | #1 AND #4 AND (Cochrane Reviews, other reviews) AND 1995–2012
#6 | #1 AND #2 AND #4 AND (Cochrane Reviews, other reviews) AND 1995–2012

Table A-8 Cochrane search terms for KQ 3: Monotherapy vs. Combination Therapy for PAH

Set # | Terms
#1 | MeSH descriptor Hypertension, Pulmonary explode all trees OR (pulmonary hypertension):ti,ab,kw OR (idiopathic pulmonary hypertension):ti,ab,kw OR (pulmonary arterial hypertension):ti,ab,kw OR (pulmonary artery hypertension):ti,ab,kw OR pah:ti,ab,kw OR ipah:ti,ab,kw
#2 | bosentan:ti,ab,kw OR ambrisentan:ti,ab,kw OR phosphodiesterase:ti,ab,kw OR sildenafil:ti,ab,kw OR tadalafil:ti,ab,kw OR (vasodilator agent):ti,ab,kw or prostaglandin:ti,ab,kw OR prostaglandins:ti,ab,kw OR prostanoid:ti,ab,kw OR prostanoids:ti,ab,kw OR epoprostenol:ti,ab,kw OR prostacyclin:ti,ab,kw OR treprostinil:ti,ab,kw OR iloprost:ti,ab,kw OR bosentan:ti,ab,kw OR ambrisentan:ti,ab,kw OR sildenafil:ti,ab,kw OR tadalafil:ti,ab,kw OR endothelins:ti,ab,kw OR endothelin:ti,ab,kw OR pde5:ti,ab,kw OR MeSH descriptor Vasodilator Agents explode all trees OR MeSH descriptor Endothelins explode all trees OR MeSH descriptor Prostaglandins explode all trees OR MeSH descriptor Hydrolases explode all trees OR MeSH descriptor Phosphodiesterase Inhibitors explode all trees
#3 | Amlodipine:ti,ab,kw OR Amrinone:ti,ab,kw OR anandamide:ti,ab,kw OR anipamil:ti,ab,kw OR azimilide:ti,ab,kw OR Bencyclane:ti,ab,kw OR benidipine:ti,ab,kw OR Bepridil:ti,ab,kw OR berbamine:ti,ab,kw OR canadine:ti,ab,kw OR (carboxyamido-triazole):ti,ab,kw OR caroverine:ti,ab,kw OR cilnidipine:ti,ab,kw OR Cinnarizine:ti,ab,kw OR clentiazem:ti,ab,kw OR Conotoxins:ti,ab,kw OR darodipine:ti,ab,kw OR dauricine:ti,ab,kw OR devapamil:ti,ab,kw OR Diltiazem:ti,ab,kw OR dimeditiapramine:ti,ab,kw OR dotarizine:ti,ab,kw OR efonidipine:ti,ab,kw OR emopamil:ti,ab,kw OR enpiperate:ti,ab,kw OR eperisone:ti,ab,kw OR falipamil:ti,ab,kw OR fantofarone:ti,ab,kw OR fasudil:ti,ab,kw OR Felodipine:ti,ab,kw OR (fenamic acid):ti,ab,kw OR Fendiline:ti,ab,kw OR Flunarizine:ti,ab,kw OR fosfedil:ti,ab,kw OR gabapentin:ti,ab,kw OR Gallopamil:ti,ab,kw OR Isradipine:ti,ab,kw OR lacidipine:ti,ab,kw OR lamotrigine:ti,ab,kw OR lercanidipine:ti,ab,kw OR Lidoflazine:ti,ab,kw OR (Magnesium Sulfate):ti,ab,kw OR manidipine:ti,ab,kw OR manoalide:ti,ab,kw OR mepirodipine:ti,ab,kw OR Mibefradil:ti,ab,kw OR monatepil:ti,ab,kw OR naftopidil:ti,ab,kw OR Nicardipine:ti,ab,kw OR Nifedipine:ti,ab,kw OR niguldipine:ti,ab,kw OR niludipin:ti,ab,kw OR nilvadipine:ti,ab,kw OR Nimodipine:ti,ab,kw OR Nisoldipine:ti,ab,kw OR Nitrendipine:ti,ab,kw OR norverapamil:ti,ab,kw OR ochratoxin:ti,ab,kw OR octylonium:ti,ab,kw OR (omega-Agatoxin):ti,ab,kw OR (omega-Conotoxin):ti,ab,kw OR (omega-Conotoxins):ti,ab,kw OR osthol:ti,ab,kw OR oxodipine:ti,ab,kw OR Perhexiline:ti,ab,kw OR pinaverium:ti,ab,kw OR piperidine:ti,ab,kw OR pranidipine:ti,ab,kw OR Prenylamine:ti,ab,kw OR (risedronic acid):ti,ab,kw OR ryodipine:ti,ab,kw OR sesamodil:ti,ab,kw OR stepholidine:ti,ab,kw OR terodiline:ti,ab,kw OR tetrahydropalmatine:ti,ab,kw OR tetrandrine:ti,ab,kw OR (tolfenamic acid):ti,ab,kw OR tranilast:ti,ab,kw OR Verapamil:ti,ab,kw OR ziconotide:ti,ab,kw OR MeSH descriptor Calcium Channel Blockers explode all trees
#4 | #1 AND (#2 OR #3) AND (Cochrane Reviews, other reviews) AND 1995–2012