# Abbreviations

6MWD: 6-minute walk distance
AHRQ: Agency for Healthcare Research and Quality
BID: two times per day
BNP: B-type natriuretic peptide
CI: confidence interval
CHF: congestive heart failure
COPD: chronic obstructive pulmonary disease
CTEPH: chronic thromboembolic pulmonary hypertension
CVD: collagen vascular disease
DLCO: diffusion capacity of the lung for carbon monoxide
FAC: fractional area change
FC: functional class
HR: hazard ratio
HRQOL: health-related quality of life
IQR: interquartile range
KQ: Key Question
MI: myocardial infarction
MIF: migration inhibitory factor
mo: month/months
mPAP: mean pulmonary artery pressure
MPI: myocardial performance index
NA: not applicable
NR: not reported
NT-proBNP: N-terminal pro-B-type natriuretic peptide
NYHA: New York Heart Association
OR: odds ratio
PAH: pulmonary arterial hypertension
PADP: pulmonary artery diastolic pressure
PASP: pulmonary artery systolic pressure
PCWP: pulmonary capillary wedge pressure
PH: pulmonary hypertension
PPH: primary pulmonary hypertension
PVR: pulmonary vascular resistance
QOL: quality of life
RA: right atrium
RAP: right atrial pressure
RHC: right heart catheterization
RIMP: right index of myocardial performance
RR: risk ratio
RV: right ventricle
RVEF: right ventricle ejection fraction
S′: tricuspid lateral annular systolic velocity
SD: standard deviation
SEM: standard error of the mean
SOE: strength of evidence
sPAP: systolic pulmonary artery pressure
SSc: systemic sclerosis
TAPSE: tricuspid annular plane systolic excursion
TDI: tissue Doppler imaging
TID: three times per day
TEP: Technical Expert Panel
TG: tricuspid gradient
TRV: tricuspid regurgitant jet velocity
VSD: ventricular septal defect
VTI_RVOT_: velocity-time integral of right ventricular outflow tract
yr: year/years