# Results

## Results of the Search

Figure 2 summarizes the search results. The literature search identified 30,902 unique citations. During the title screening, we excluded 21,687 citations. During the abstract screening, we excluded 7,008 citations that met at least one of the exclusion criteria. During article screening, we excluded an additional 2106 articles that did not meet one or more of the inclusion criteria. (Appendix D) One hundred and one articles were included in the review.

Figure 2 Summary of the literature search

HIT = heparin induced thrombocytopenia; KQ = Key Question; VTE = venous thromboembolism

* Total exceeds the # in the exclusion box because reviewers were allowed to mark more than 1 reason for exclusion.

Figure 2 describes the flow of articles through the screening and review process. 39,203 unique articles were identified in the search, 30,902 were screened out at the title level, 9215 were screened out at the abstract level, 2106 were excluded on full text review and 101 articles were included in the report.

## Description of Types of Studies Retrieved

Of the 101 articles, only 6 were randomized controlled trials. Of the included studies, 58 studies addressed Key Question (KQ) 1 (patients with trauma), 8 studies addressed KQ 2a (patients with traumatic brain injury), 5 studies addressed KQ 2a (patients with traumatic brain injury–timing of initiation and duration of pharmacological prophylaxis), 1 study addressed KQ 3 (patients with burns), 2 studies addressed KQ 5 (patients receiving antiplatelet therapy), 21 studies addressed KQ 6 (patients having bariatric surgery), 2 study addressed KQ 7 (obese and underweight patients), and 5 studies addressed KQ 8 (patients with acute kidney injury and renal impairment). There were no studies identified that addressed KQ 4 (patients with liver failure).

### Scientific Information Packets (SIPs)

As part of the grey literature search, pharmaceutical companies with drugs or devices included in this review were asked to provide information about pertinent studies conducted with their products (published, unpublished, and clinical trials). Three companies responded with letters indicating that no relevant studies had been conducted. Four companies provided comprehensive scientific information packets (SIP), which identified potentially relevant studies; these citations were carefully crosschecked against our existing reference database (to avoid redundancy), yielding six new references, none of which were applicable to this review. One additional SIP was submitted by the American Association of Neurological Surgeons; however, this was a chemoprophylaxis protocol and therefore did not meet the eligibility criteria for this review (Appendix F).

### Clinical Trials

The U.S. clinical trials registry (clinicaltrials.gov) was used to identify additional trials pertinent to this review. Using search terms “venous thromboembolism prophylaxis” and “inferior vena cava filter”, we identified 339 clinical trials in adults and seniors until July 2012. Two national IVC filter registries who were recruiting participants were also identified. (Appendix I) Many of the trials were still recruiting participants. Only 15 trials were eligible for review. Five trials were completed. However, results were available for only two trials included in our review.50,51

## Key Question 1 What are the comparative effectiveness and safety of inferior vena cava filters to prevent pulmonary embolisms in hospitalized patients with trauma?

### Key Points and Evidence Grades

In hospitalized patients with trauma:

- The strength of evidence is low that IVC filter placement is associated with a lower incidence of PE compared with no IVC filter placement.
- The strength of evidence is low that IVC filter placement is associated with a lower incidence of fatal PE in hospitalized patients with trauma compared with no IVC filter placement.
- The strength of evidence is insufficient that IVC filter placement is associated with less mortality in hospitalized patients with trauma compared with no IVC filter placement.
- The strength of evidence is insufficient that IVC filter placement is associated with a higher incidence of DVT compared with no IVC filter placement
- The strength of evidence is insufficient that IVC filter placement is associated with filter related thrombosis in hospitalized patients with trauma
- The strength of evidence is insufficient that IVC filter placement is associated with filter tilt/migration in hospitalized patients with trauma

### Study Characteristics

#### Randomized Controlled Trials and Controlled Observational Studies

Eight controlled studies evaluated the effect of IVC filters versus no filters on VTE events in adult trauma patients 52-59 (Table 4). Two controlled studies also compared IVC filters with IVC filters60,61 (Table 5).

Table 4 Study characteristics for controlled studies (IVCF vs. control) for KQ 1

Author, Year | Study Design | Arm | Sample Size (N) | Mean Age, Years | % Male | Mean ISS Scores
Rajasekhar A, 2011^52^ | RCT | IVCF | 18 | 41.2 | 72.2 | 26.6
Rajasekhar A, 2011^52^ | RCT | Control | 16 | 53.7 | 62.5 | 24.1
Rogers FB, 1997^53^ | PC | IVCF | 35 | 58.4 | NR | 22.8
Rogers FB, 1997^53^ | PC | Control | 905 | 38.9 | NR | 9.83
Gosin JS, 1997^56^ | PC | IVCF | 99 | 42.6 | 71.7 | 23.4
Gosin JS, 1997^56^ | PC | Control | 249 | NR | NR | NR
Rogers FB, 1995^54^ | Historical comparison | IVCF | 63 | 38.9 | 73.0 | 31.5
Rogers FB, 1995^54^ | Historical comparison | Controls | 2525 | NR | NR | NR
Wilson JT, 1994^55^ | Historical comparison | PGF | 15 | 31.4 | NR | 30.0
Wilson JT, 1994^55^ | Historical comparison | Control | 111 | 30.0 | NR | 29.0
Gorman PH, 2009^57^ | RC | IVCF | 54 | 37.1 | 96.0 | NR
Gorman PH, 2009^57^ | RC | Control | 58 | 48.1 | 69.0 | NR
Rodriguez JL, 1996^59^ | PC | IVCF | 40 | 44.0 | 58.0 | 31 .0
Rodriguez JL, 1996^59^ | PC | Control | 80 | 41.0 | 68.0 | 29.0
Khansarinia S, 1995^58^ | Historical comparison | PGF | 108 | 35.9 | 76.0 | 28.0
Khansarinia S, 1995^58^ | Historical comparison | Control | 216 | 38.3 | 75.5 | 25.4

IVCF = inferior vena cava filter; PGF = prophylactic Greenfield filter; RCT = randomized controlled trial; PC = prospective cohort; RC = retrospective cohort

Table 5 Study characteristics for controlled studies of an inferior vena cava filter (IVCF) versus IVCF for KQ 1

Author, Year | Study Design | Filter Type^†^ | Sample Size (N) | Mean Age | % Male | Mean ISS | Filter Retrieval Rate %
Rosenthal D, 2009^60,*^ | RC | Gunther Tulip | 97 | 44 | 58.2 | 28.5 | 54
Rosenthal D, 2009^60,*^ | RC | Celect Retrievable | 90 | 44 | 58.2 | 28.5 | 84
Keller IS, 2007^61^ | RC | Gunther Tulip | 92 | 45.6 | 69.6 | NR | 49
Keller IS, 2007^61^ | RC | OptEase | 80 | 47.8 | 58.8 | NR | 70

NR = not reported; RC = retrospective cohort

* Study did not report characteristics by treatment group.

† Retrievable and non-retrievable filters.

One was an RCT,52 three were prospective cohort studies with concurrent comparison groups,53,56,59 three were prospective cohort studies with historical controls,54,55,58 and one was a retrospective cohort study.57 The duration of follow up was 6 months in the RCT. All studies were within single institutions in North America. Only one study reported their funding source. This study was funded by industry.

#### Uncontrolled Studies

Forty-eight uncontrolled studies evaluated the use of IVC filters in hospitalized patients with trauma.34,62-108 They were conducted in North America,34,62-64,66,67,70-72,75-80,82-108 Europe,73,74,81 Asia,69 and Australia.65,68 Of these 48 studies, there were 36 cohort studies.34,62,64,65,67,69-72,74-84,87,89,91,94-97,99-104,106-108 There were13 prospective cohort studies, and the remaining were retrospective cohorts. There was one combined retrospective review and prospective study.104 There were six case series66,68,73,90,92,98 and six case reports.63,85,86,88,93,105 These studies enrolled a median of 99 patients (range, 3 to 310) in the cohort studies, 30 patients (range, 8 to 249) in the case series, and one patient (range, 1 to 2) in the case reports. Four studies enrolled men only,85,86,93,103 and two studies enrolled women only.65,105 The majority followed participants during the period of hospitalization until discharge, with only a few cohorts following patients beyond discharge (Table 6).

Table 6 Study characteristics for uncontrolled studies of IVC filters in trauma

Author, Year | Study Type | Sample Size (N) | Mean Age, Years | % Male | Filter Retrieval Rate n, (%)
O'Keefe T, 2011^62^ | RC | 91 | NR | 70 | (47)
Shang EK, 2011^63^ | Case report | 1 | 46 | 0 | NR
Smooth RL, 2010^108^ | RC | 226 | 49 | 61.1 | NR
Roberts A, 2010^64^ | RC | 45 | 39.7 | 82.2 | 17 (37)
Doody O, 2009^65^ | RC | 115 | 47.97 | 63.4 | 57 (49.6)
Phelan HA, 2009^66^ | Series | 82 | 34.1 | 63.4 | NR
Cherry RA, 2008^34^ | PC | 244 | 43.8 | 63.5 | 82/140 (58.6)
Hermsen JL, 2008^67^ | RC | 74 | 38.4 | 68 | 30/39 (77)
Lo CH, 2008^68^ | Series | 17 | 37 | 70.6 | 13/16
Mahier A, 2008^69^ | RC | 80 | 38.5 | 66 | 29 (36)
Zakhary EM, 2008^70^ | RC | 122 | 38.5 | 70.1 | 47/116 (40.5)
Karmy-Jones R, 2007^107^ | RC | 310 | NR | NR | NR
Rosenthal D, 2007^106^ | RC | 105 | NR | NR | 91/105 (86.7)
Binkert CA, 2006^71^ | RC | 13 | 46.2 | 46.2 | 13
Gonzalez RP, 2006^72^ | PC | 134 | 38.6 | NR | NR
Meier C, 2006^73^ | Series | 37 | 35 | 62 | 32 (86)
Meier C, 2006^74^ | RC | 95 | 38 | 70.5 | 65/67 (97)
Rosenthal D, 2006^75^ | RC | 127 | 42 | 60.6 | 66 (60)
Stefanidis D, 2006^76^ | PC | 83 | 43 | 71 | 47 (57)
Rosenthal D, 2005^77^ | PC | 103 | 40 | 62.1 | 44
Hoff WS, 2004^78^ | PC | 35 | NR | 71.4 | 18 (51.4)
Rosenthal D, 2004^79^ | RC | 94 | 38 | 60.6 | 31
Duperier T, 2003^80^ | RC | 133 | NR | NR | NR
Kurtoglu M, 2003^81^ | PC | 11 | NR | NR | NR
Offner PJ, 2003^82^ | PC | 44 | 37 | 55 | NR
Carlin AM, 2002^83^ | RC | NR | NR | NR | NR
Conners MS, 2002^84^ | RC | 284 | 41 | 71 | NR
Bochicchio GV, 2001^85^ | Case report | 1 | 48 | 100 | NR
Rogers F, 2001^86^ | Case report | 1 | 48 | 100 | NR
Sekharan J, 2001^87^ | RC | 33 | 38.1 | 75.8 | NR
Sing RF, 2001^88^ | Case report | 2 | 54 | 50 | NR
Sing RF, 2001^89^ | PC | 158 | 42.2 | 71.5 | NR
Greenfield LJ, 2000^90^ | Series | 249 | 43 | 61.8 | NR
Wojcik R, 2000^91^ | RC | 105 | 54.8 | 71.4 | NR
Benjamin ME, 1999^92^ | Series | 23 | 46 | 86.95 | NR
Hughes GC, 1999^93^ | Case report | 2 | 32.5 | 100 | NR
Langan EM, 1999^94^ | PC | NR | NR | NR | NR
McMurtry AL, 1999^95^ | RC | 248 | 33.7 | 68.1 | NR
O'Keefe T, 2011^62^ | RC | 91 | NR | 70 | (47)
Shang EK, 2011^63^ | Case report | 1 | 46 | 0 | NR
Smooth RL, 2010^108^ | RC | 226 | 49 | 61.1 | NR
Roberts A, 2010^64^ | RC | 45 | 39.7 | 82.2 | 17 (37)
Doody O, 2009^65^ | RC | 115 | 47.97 | 63.4 | 57 (49.6)
Phelan HA, 2009^66^ | Series | 82 | 34.1 | 63.4 | NR
Cherry RA, 2008^34^ | PC | 244 | 43.8 | 63.5 | 82/140 (58.6)
Hermsen JL, 2008^67^ | RC | 74 | 38.4 | 68 | 30/39 (77)
Lo CH, 2008^68^ | Series | 17 | 37 | 70.6 | 13/16
Mahier A, 2008^69^ | RC | 80 | 38.5 | 66 | 29 (36)
Zakhary EM, 2008^70^ | RC | 122 | 38.5 | 70.1 | 47/116 (40.5)
Karmy-Jones R, 2007^107^ | RC | 310 | NR | NR | NR
Rosenthal D, 2007^106^ | RC | 105 | NR | NR | 91/105 (86.7)
Binkert CA, 2006^71^ | RC | 13 | 46.2 | 46.2 | 13
Gonzalez RP, 2006^72^ | PC | 134 | 38.6 | NR | NR
Meier C, 2006^73^ | Series | 37 | 35 | 62 | 32 (86)
Meier C, 2006^74^ | RC | 95 | 38 | 70.5 | 65/67 (97)
Rosenthal D, 2006^75^ | RC | 127 | 42 | 60.6 | 66 (60)
Stefanidis D, 2006^76^ | PC | 83 | 43 | 71 | 47 (57)
Rosenthal D, 2005^77^ | PC | 103 | 40 | 62.1 | 44
Hoff WS, 2004^78^ | PC | 35 | NR | 71.4 | 18 (51.4)
Rosenthal D, 2004^79^ | RC | 94 | 38 | 60.6 | 31
Duperier T, 2003^80^ | RC | 133 | NR | NR | NR
Kurtoglu M, 2003^81^ | PC | 11 | NR | NR | NR
Offner PJ, 2003^82^ | PC | 44 | 37 | 55 | NR
Carlin AM, 2002^83^ | RC | NR | NR | NR | NR
Conners MS, 2002^84^ | RC | 284 | 41 | 71 | NR
Bochicchio GV, 2001^85^ | Case report | 1 | 48 | 100 | NR
Rogers F, 2001^86^ | Case report | 1 | 48 | 100 | NR
Sekharan J, 2001^87^ | RC | 33 | 38.1 | 75.8 | NR
Sing RF, 2001^88^ | Case report | 2 | 54 | 50 | NR
Sing RF, 2001^89^ | PC | 158 | 42.2 | 71.5 | NR
Greenfield LJ, 2000^90^ | Series | 249 | 43 | 61.8 | NR
Wojcik R, 2000^91^ | RC | 105 | 54.8 | 71.4 | NR
Benjamin ME, 1999^92^ | Series | 23 | 46 | 86.95 | NR
Hughes GC, 1999^93^ | Case report | 2 | 32.5 | 100 | NR
Langan EM, 1999^94^ | PC | NR | NR | NR | NR
McMurtry AL, 1999^95^ | RC | 248 | 33.7 | 68.1 | NR
Tola JC, 1999^96^ | RC | NR | NR | NR | NR
Rogers FB, 1997^97^ | PC | 132 | 39.1 | 73 | NR
Sing RF,1997^98^ | Series | 8 | NR | 87.5 | NR
Nunn CR, 1997^99^ | PC | 49 | 31 | NR | NR
Patton JH Jr, 1996^100^ | RC | 110 | 47.2 | 61.8 | NR
Zolfaghari D, 1995^101^ | RC | 45 | NR | 51.1 | NR
Leach TA, 1994^102^ | PC | 201 | NR | 73 | NR
Millward SF, 1994^103^ | PC | 3 | 36 | 100 | NR
Rogers FB, 1993^104^ | PC/RC | 34 | 41.6 | NR | NR
Bach JR, 1990^105^ | Case report | 1 | NR | 0 | NR

ISS = Injury Severity Score; IVC = inferior vena cava; N = number; NR = not reported; PC = prospective cohort; RC = retrospective cohort

### Participant Characteristics

#### Randomized Controlled Trials and Controlled Observational Studies

The mean age of participants in the RCT was 53.7 years and 41.2 years in the control and IVC filter groups, respectively.52 Of the enrolled patients, 62.5 and 72.2 percent were men, respectively. The patients in the controlled observational studies were largely aged 35 to 50 years old, with men comprising roughly 60 to 75 percent of the studied population.

Only two studies reported exclusion criteria. The trial excluded pregnant patients, patients with previously placed IVC filters, those with a contraindication to filter placement, and patients that were terminally ill or not expected to survive for more than 24 hours.52 A second study excluded elderly patients with isolated rib fractures.54 The remaining studies did not report exclusion criteria. Most studies did not describe the race of the patients.

#### Uncontrolled Studies

The mean age of patients in the uncontrolled studies was roughly 40 years. The majority of studies enrolled both men and women with a preponderance of men in each study population. The mean injury severity scores were variable and ranged from 23.1^95^ to 38^74^ across studies, reflecting varying degrees of trauma severity. The inclusion and exclusion criteria varied widely (Table 6).

### Intervention Characteristics

#### Randomized Controlled Trials and Controlled Observational Studies

Eight studies evaluated the comparative effectiveness of IVC filters versus no IVC filters in trauma patients.52-59 All studies analyzed patients in two groups. One group of patients received “standard” therapy alone, and the other group received IVC filters in addition to “standard” therapy. The definitions of standard therapy varied. The most common standard therapy was a combination of venous compression devices with subcutaneous LMWH.52,55-58 Two studies defined standard therapy as venous compression devices alone.53,54 One study provided various VTE prophylaxis regimens (some venous compression devices and others LMWH).59

Two retrospective cohort studies compared the effectiveness of different kinds of IVC filters on the prevention of VTE in hospitalized patients with trauma.60,61 One study compared the Gunther Tulip filter with the Celect filter.60 Both of these filters are temporary and clinicians placed them bedside in the ICU. The second study compared the Gunther Tulip filter with the Optease filter.61 Both of these filters are temporary and interventional radiologists placed them in angiography suites.

#### Uncontrolled Studies

The uncontrolled IVC filter studies varied in the protocol used for VTE prophylaxis. Thirty-three studies used IVC filters only34,62,65-67,69-73,76-79,83-86,88-91,93,96-98,101-103,105-108 and 15 studies involved the use of concurrent therapy with a pharmacological agent, ,63,64,81,99 a mechanical agent,104 or a combination of a pharmacological agent and a mechanical agent.68,74,75,80,82,87,92,94,95,100 The brand of filters varied and included Bard Recovery, Celect^®^, Cook Bird's nest, G2^®^, Gianturco-Roehm Bird's Nest^®^, Greenfield Stainless Steel^®^, Greenfield Titanium^®^, Gunther Tulip^®^, OPTEASE^®^, Poliser, Recovery, Simon Nitinol^®^, TRAPEASE^®^, VenaTech LGM^®^, and Vena Tech LP^®^ types. One retrospective, single-center, uncontrolled study compared outcomes by the specific filter type, which included both permanent (Greenfield, VenaTech, TrapEase) and retrievable (Gunther Tulip, and Recovery IVC) filters.108 The multi-center study compared three retrievable IVC filters (Gunter-Tulip, Recovery, and OPTEASE).107 The type of filter was retrievable in 16 studies, 64,65,67-71,73,75-77,79,82,88,103,107 permanent in three studies,66,95,105, and both permanent and retrievable in five studies.34,74,81,106,108 Twenty-four studies did not specify the type of filters used.62,63,72,78,80,83-87,89-94,96-102,104 Two uncontrolled studies also reported data on outcomes by different types of IVC devices.107,108

### Ascertainment

#### Randomized Controlled Trials and Controlled Observational Studies

Most studies relied on duplex ultrasonography for diagnosis of DVT, although some older studies used outdated modalities such as impedance plethysmography (IPG).53,55 For the diagnosis of PE, most studies used computed tomography angiography. Some studies used angiography for the diagnosis of PE. Infrequently, studies used ventilation/perfusion scans for PE diagnosis.

#### Uncontrolled Studies

Most of the uncontrolled studies used objective measures typically applied in clinical practice to document the occurrence of these events (duplex ultrasonography of DVT, computed tomography angiography, ventilation-perfusion for PE), while only few reports used other measures, such as plethysomography, venography, and autopsy, when possible.

### Outcomes

Our results for the relative risk meta-analysis on the outcome of PE, fatal PE, mortality, DVT and filter related thrombosis among filters vs no filters in patients with trauma in controlled studies are shown in Figures 3–6. The results for the proportion and 95% Confidence intervals on the outcome of PE, mortality and DVT in uncontrolled studies in patients with trauma are shown in Figures 7–9.

Figure 3 Relative risk forest plot (random effects) of inferior vena cava filters versus no filters in trauma on PE

CI = confidence interval; IVCF = inferior vena cava filter; PE = pulmonary embolism; RR = relative risk

Figure 3 describes the relative risk of PE among patients with trauma who received IVC filters vs no filters. Six studies are included in this figure

Figure 4 Relative risk forest plot (random effects) of inferior vena cava filters versus no filters in trauma on fatal PE

CI = confidence interval; IVCF = inferior vena cava filter; PE = pulmonary embolism; RR = relative risk

Figure 4 describes the relative risk of Fatal PE among patients with trauma who received IVC filters vs no filters. Three studies are included in this figure

Figure 5 Relative risk forest plot (random effects) of inferior vena cava filters versus no filters in trauma on mortality

CI = confidence interval; IVCF = inferior vena cava filter; RR = relative risk

Figure 5 describes the relative risk of Mortality among patients with trauma who received IVC filters vs no filters. Three studies are included in this figure

Figure 6 Relative risk forest plot (random effects) of inferior vena cava filters versus no filters in trauma on DVT

CI = confidence interval; DVT = deep vein thrombosis; IVCF = inferior vena cava filter; RR= relative risk

Figure 6 describes the relative risk of DVT among patients with trauma who received IVC filters vs no filters. Three studies are included in this figure

Figure 7 Proportion plot for PE in uncontrolled studies of inferior vena cava filters (random effects)

Figure 7 describes the proportion and 95 % CI of patients with PE in uncontrolled studies of IVC filters among patients with trauma. Thirty studies are included in this figure

Figure 8 Proportion plot of mortality in uncontrolled filter studies (random Effects)

Figure 8 describes the proportion and 95 % CI of patients with mortality in uncontrolled studies of of IVC filters among patients with trauma. Twenty-five studies are included in this figure

Figure 9 Proportion of deep vein thrombosis in uncontrolled studies of inferior vena cava filters

Figure 9 describes the proportion and 95 % CI of patients with mortality in uncontrolled studies of IVC filters among patients with trauma. Twenty one studies are included in this figure

#### Pulmonary Embolism

##### Inferior Vena Cava Filter Versus No Inferior Vena Cava Filter

We excluded the two studies conducted by Rogers et al from the meta-analysis and strength of evidence ratings as we considered them to have fatal flaws.53,54 The first Rogers study54 was excluded because of concerns about data-duplication. Rogers et al 1997 53 may have contained overlapping participants with another study by the same authors.54 Another study by Rogers study was excluded from the meta-analysis and strength of evidence ratings because of severe prognostic imbalance in Injury Severity Scores (ISS) (mean ISS 22.8 vs. 9.3 in filter vs. control group. 53 In the only included small RCT, there was no statistical difference in the incidence of PE between the two groups.52 There were no PEs in the IVC filter group and one PE among patients without filters. Five of the seven observational studies reported lower PE rates with IVC filter placement;54-56,58,59 four of these were statistically significant findings. Two studies reported higher PE rates with IVC filter use.53,57 However, one had a non-significant finding with a single PE in each group (but many more patients in its control arm).53 One study of spinal cord injury patients found a single patient who had a PE diagnosed after a clinician placed an IVC filter57(Table 7).

Table 7 Outcomes data for controlled studies (inferior vena cava filter vs. control)

Author, Year | Arm | Sample Size (N for Analysis) | Total DVT n | Total Mortality n | Fatal PE n | PE n
Rajasekhar A, 2011^52^ | IVCF | 18 | 1 | 1^*^ | 0 | 0
Rajasekhar A, 2011^52^ | Control | 16 | 0 | 0 | 0 | 1
Rogers FB, 1997^53^ | IVCF | 35 | NR | 4 | NR | 1
Rogers FB, 1997^53^ | Control | 905 | NR | 46 | NR | 1
Gosin JS, 1997^56^ | IVCF | 99 | NR | NR | NR | 0
Gosin JS, 1997^56^ | Control | 249 | NR | NR | NR | 12
Rogers FB, 1995^54^ | IVCF | 63 | 19 | 3 | 1 | 1
Rogers FB, 1995^54^ | Historical Controls | 2525 | NR | 28 | 7 | 25^†^
Wilson JT, 1994^55^ | IVCF | 15 | 0 | NR | 0 | 0
Wilson JT, 1994^55^ | Control | 111 | NR | NR | 3 | 8^‡^
Gorman PH, 2009^57^ | IVCF | 54 | 11 | NR | NR | 1
Gorman PH, 2009^57^ | Control | 58 | 3 | NR | NR | 0
Rodriguez JL, 1996^59^ | IVCF | 40 | 6 | 2 | 0 | 1
Rodriguez JL, 1996^59^ | Control | 80 | 15 | 13 | 8 | 14
Khansarinia S, 1995^58^ | PGF^§^ | 108 | NR | 18 | 0 | 0
Khansarinia S, 1995^58^ | Control | 216 | NR | 47 | 9 ** | 13Ω

DVT = deep vein thrombosis; IVCF = inferior venous cavity filter; PE = pulmonary embolism

* Non-VTE-related death.

† 25-total PEs in historical control group, of these 7 were fatal PEs;

‡ 8- total PEs, of these 3 were fatal PEs;

§ PGF (Prophylactic Greenfield Filter).

** Statistically significant difference in fatal PE, P = 0.03;

Ω 13-total PEs, of these 9 were fatal PEs.

We included six controlled studies for the meta-analysis on PE outcomes.52,55-59 Our meta-analysis showed a precise and consistent evidence of reduction in PE with IVC filters compared with no IVC filters without any evidence of statistical heterogeneity (Figure 3, relative risk [RR]: 0.20, 95% CI:0.06-0.70; I^2^=0%). Our results were robust to alternative approaches for continuity correction and showed largely similar results (Appendix H).

##### Inferior Vena Cava Filter Versus Inferior Vena Cava Filter

Two studies reported on the outcome of PE between Gunther Tulip vs Celect filters60 and Gunther Tulip vs OPTEASE filters.61 There were no statistically significant differences in the incidence of PE in the studies although the incidence of PE was higher in the Gunther Tulip arm compared with the OPTEASE arm.61 Another uncontrolled study which also reported on differences between filter types found no difference in “breakthrough” PE rates between filters (Table 8).107

Table 8 VTE outcomes and complications for comparison of different types of IVC filters

Source | Filter Type | Sample Size (N for Analysis) | Filter Retrieval Rate (%) | Total DVT (n) | Total Mortality (%) | PE (n)
Rosenthal D, 2009^60,#^ | Gunther Tulip | 97 | 54 | 2 | 29^*^ | 1
Rosenthal D, 2009^60,#^ | Celect Retrievable | 90 | 84 | NR | 11^*^ | 1
Keller IS, 2007^61,##^ | Gunther Tulip Filter | 92 | 49 | 1 | NR | 2
Keller IS, 2007^61,##^ | OptEase Filter | 80 | 70 | NR | NR | 1

DVT = deep vein thrombosis; N = number; PE = pulmonary embolism

* Non-VTE-related death.

# Rosenthal et al. also reported on complications for Gunther Tulip compared with Celect filters: groin hematomas 4.1 % vs. 1.1% and Filter misplacement/migration: 6.2% vs. 1.1%.

## Keller et al also reported on complications for Gunther Tulip compared with Optease: Filter migration: 1.1% vs. 0% Caval occlusion: 7 % vs. 3%.

##### Uncontrolled Studies of Inferior Vena Cava Filters

Of the 40 total studies, studies reported the occurrence of PE, with percentages ranging from 0 to 5.8 percent, with the vast majority reporting PE proportions of 2 percent or less.34,63,65-68,71,73-75,76-79,80-97, 99-106,108 Figure 7 describes the proportion and 95% CI of patients with PE in uncontrolled studies of IVC filters among patients with trauma. Most of these studies had limited follow up. The longest study reported follow up of 7 years for 97 patients, with a PE proportion of 2.1 percent.66 One study reported only the total PE as the primary outcomes, with a prevalence of 3.5 percent among 226 patients (Table 9).108

Table 9 Outcomes data for uncontrolled studies of inferior vena cava filters

Author, Year | Total DVT n (%) | Total Mortality n (%) | PE n (%)
O'Keefe T, 2011^62^ | 10 (15) | NR | NR
Smooth RL, 2010^108^ | NR | NR | 8 (4)
Roberts A, 2010^64^ | 0 (0) | NR | NR
Doody O, 2009^65^ | NR | NR | 1 (0.9)
Phelan HA, 2009^66^ | NR | 15 (15.5) | 2 (2.1)
Cherry RA, 2008^34^ | 22 (9) | NR | 4 (1.6)
Hermsen JL, 2008^67^ | NR | 4 (4.3) | 3 (3.2)
Lo CH, 2008^68^ | NR | 1 (5.9) | 1 (5.9)
Mahier A, 2008^69^ | NR | NR | NR
Zakhary EM, 2008^70^ | NR | NR | NR
Karmy-Jones R, 2007^107^ | 18 (20) | NR | NR
Gonzalez RP, 2006^72^ | 0 (0) | NR | NR
Meier C, 2006^73^ | NR | 1 (2.7) | 1 (2.7)
Meier C, 2006^74^ | 2 (2.1) | 7 (7.4) | 1 (1.1)
Rosenthal D, 2006^75^ | NR | 39 (30.7) | 1 (0.8)
Stefanidis D, 2006^76^ | NR | 3 (4) | 0 (0)
Rosenthal D, 2005^77^ | 2 (1.9) | 24 (23.3) | 1 (1)
Hoff WS, 2004^78^ | 3 (8.6) | NR | 0 (0)
Rosenthal D, 2004^79^ | NR | 19 (20.2) | 1 (1.1)
Duperier T, 2003^80^ | 31 (23.3) | 0 (0) | 1 (0.8)
Kurtoglu M, 2003^81^ | 0 (0) | NR | 0 (0)
Offner PJ, 2003^82^ | NR | 0 (0) | 0 (0)
Carlin AM, 2002^83^ | 5 (6.4) | 2 (4) | 0 (0)
Conners MS, 2002^84^ | NR | 36 (12.7) | 1 (0.4)
Sekharan J, 2001^87^ | 2 (6.1) | 18 (17) | 0 (0)
Sing RF, 2001^89^ | 8 (5.1) | 18 (11.4) | 1 (0.6)
Greenfield LJ, 2000^90^ | 16 (10.8) | 39 (15.6) | 3 (1.5)
Wojcik R, 2000^91^ | NR | 13 (6.8) | 0 (0)
Benjamin ME, 1999^92^ | 0 (0) | 3 (13) | 0 (0)
Langan EM, 1999^94^ | 24 (12.8) | 27 (14.4) | 1 (0.5)
McMurtry AL, 1999^95^ | 6 (2.4) | 31 (13) | 4 (1.6)
Tola JC, 1999^96^ | NR | 4 (0.2) | 0 (0)
Rogers FB, 1997^97^ | 12 (9.1) | 6 (4.4) | 3 (2.3)
Sing RF,1997^98^ | 1 (12.5) | 1 (12.5) | NR
Nunn CR, 1997^99^ | 1 (2.0) | NR | 0 (0)
Patton JH Jr, 1996^100^ | 7 (6.4) | 22 (20) | 0 (0)
Zolfaghari D, 1995^101^ | - NR | 1 (1.2) | 0 (0)
Leach TA, 1994^102^ | 1 (0.5) | 1 (0.5) | 0 (0)
Millward SF, 1994^103^ | NR | 0 (0) | 0 (0)
Rogers FB 1993^104^ | 6 (17.6) | 2 (5.9) | 0 (0)

DVT = deep vein thrombosis; NR = not reported; PE = pulmonary embolism

#### Fatal Pulmonary Embolism

##### Randomized Controlled Trials and Controlled Observational Studies

We included four studies that reported on this outcome.52,55,58,59 In all the included studies there were no PEs in the intervention arm. There was no VTE related deaths in the trial.52 A prospective cohort study with historical controls identified a statistically significant increase in the incidence of fatal PE in patients that did not receive IVC filters (4 percent vs. zero percent. p-value < 0.0.3).58 There were no differences in fatal PE in two prospective cohort studies that compared IVC filters with compression devices.53,54

Figure 4 shows the relative risk meta-analysis on the outcome of fatal PE (RR, 0.09 (0.01 to 0.81). There was a precise and consistent evidence of reduction in fatal PE with IVC filters compared with no IVC filters, without any evidence of statistical heterogeneity (RR, 0.09,95% CI 0.01 to 0.81; I^2^=0%) However, sensitivity analysis with alternative continuity corrections were not uniformly robust for the outcome of fatal PE (Appendix H). The Peto OR approach continued to show a statistically significant reduction in fatal PE, Peto OR, 0.22 (95% CI = 0.08 to 0.58), similar to the significant reduction seen in the primary analysis. Alternative continuity corrections such as the 0.5 correction, RR 0.22 (95% CI = 0.04 to 1.16) or 0.01 correction, RR, 0.01 95% CI = 0 to 425.5) were not statistically significant. Given the fragility of these findings the significant reductions in fatal PE should be viewed with caution.

##### Uncontrolled Studies

Among the uncontrolled studies that reported on prophylactic IVC filters in hospitalized patients with trauma, five studies reported on the outcome of fatal PE.74,80,92,95,97 Four studies reported no deaths due to PE.

#### Mortality

##### Randomized Controlled Trials and Controlled Observational Studies

###### Inferior Vena Cava Filters Versus No Inferior Vena Cava Filters

We included three studies that reported on mortality in the meta-analysis.52,58,59 Figure 5 shows the relative risk meta-analysis on the outcome of mortality RR, 0.70 (0.40 to 1.23; I^2^=6.7%.

Our results were robust to alternative approaches for continuity correction and showed largely similar results (Appendix H). There were no differences observed in the trial with regards to VTE and non-VTE mortality between groups.52 In another prospective cohort study, all-cause mortality was higher in the IVC filters group as compared with the compression device only group (11.4 percent vs. 5.1 percent).53 Similarly, in another study, total mortality was higher in the IVC filter group than the compression device only group,54 while higher mortality was reported in the control group compared with IVC filter in another study.58

###### Inferior Vena Cava Filters Versus Inferior Vena Cava Filters

The study by Rosenthal et al. defined a secondary outcome as total mortality unrelated to VTE. In this study, the mortality was higher in the Gunther tulip group than in the Celect group (29 percent vs. 11 percent).60

##### Uncontrolled Studies

Thirty studies reported on mortality in hospitalized patients with trauma. Figure 10 describes the proportion and 95% CI of patients with mortality in uncontrolled studies of IVC filters among patients with trauma. The mortality rates were variable and ranged from 0 percent to as high as 31 percent.82 92

Figure 10 Studies reporting percentage of patients developing thromboembolic outcomes in early (<72 hours) and late prophylaxis groups (>72 hours)

DVT = deep vein thrombosis; PE = pulmonary embolism; VTE = venous thromboembolism

Fig 10: Studies reporting percent of patients developing thromboembolic outcomes in early (<72 hours) and late prophylaxis groups (>72 hours)

#### Deep Vein Thrombosis

##### Randomized Controlled Trials and Controlled Observational Studies

###### Inferior Vena Cava Filters Versus No Inferior Vena Cava Filters

Three studies reported on DVT outcomes.52,57,59 In the RCT, there were no significant differences in the incidence of DVT between the two groups. There was one DVT in the IVC filter group and none in the control group.52 One retrospective cohort study reported a statistically significant increase in the incidence of DVT in the IVC filter group (20.4 percent vs. 5.2 percent, p value <0.021).57 One additional study found a non-significant difference in DVT incidence, which was lower in the IVC filter group (15 percent vs. 19 percent).59

Figure 6 shows the relative risk meta-analysis on the outcome of DVT (RR 1.76, 95% CI = 0.49 to 6.18:p=0.38). This demonstrate the substantial statistical heterogeneity among the included studies with an I^2^=56.8%. The results of sensitivity analysis to examine the influence of alternative continuity corrections were largely similar (Appendix H).

###### Inferior Vena Cava Filters Versus Inferior Vena Cava Filters

Two studies reported on the outcome of DVT between Gunther Tulip vs Celect filters60 and Gunther Tulip vs OPTEASE filters.61 Although the data were sparse both studies reported a higher incidence of DVT in the Gunther Tulip arm. There were no statistically significant differences in the incidence of DVT.

##### Uncontrolled Studies

Twenty-three studies reported the total DVT events, with proportions ranging from 0 to 23 percent, with a total sample size ranging between one to 249 patients.34,62,63,74,77,78,80,81,83,87,89-92,94,95,97-100,102,104,107 Figure 9 describes the proportion and 95% CI of patients with DVT in uncontrolled studies of IVC filters among patients with trauma.

Nine studies reported lower extremity DVT events with sample sizes of one to 122 patients.64,65,69,70,72,75,79,93,107 The follow up was limited to a hospital stay or up to 2 months, except for one study that had a 1-year followup.70 The event rates ranged between 0 and 7.8 percent. Only two studies reported upper-extremity DVT events.68,76 Those two studies had 17 and 83 patients, respectively, and one upper extremity DVT occurred in either group, corresponding to rates of 5.8 and 1.2 percent, respectively.

#### Filter Complications

##### Randomized Controlled Trials and Controlled Observational Studies

###### Inferior Vena Cava Filters Versus No Inferior Vena Cava Filters

Four comparative studies reported data on filter complications53,54,58,59 The majority of the adverse events were related to filter complications, such as tilting,53 migration,110 IVC thrombosis and insertion-site thrombosis.54 Of these, insertion-site thrombosis was the most common, occurring in 5.7 percent of patients in one study.53 Other filter complications such as tilting and migration occurred less frequently, occurring in 1 to 2 percent of patients in most studies (Table 10).

Table 10 Adverse events for controlled studies (inferior vena cava filter vs. control)

Author, Year | Arm | Sample Size (n) | Filter Related Complications
Author, Year | Arm | Sample Size (n) | Filter Tilt (%) | Filter Migration (%) | Filter Thrombosis (%) | IVC Thrombosis/Occlusion (%)
Rogers FB, 1997^53^ | IVCF | 35 | 1 | NR | 2 | NR
Rogers FB, 1997^53^ | Control | 905 | NR | NR | NR | NR
Rogers FB, 1995^54^ | IVCF | 63 | NR | NR | 2 | 2
Rogers FB, 1995^54^ | Control | 3088 | NR | NR | NR | NR
Rodriguez JL, 1996^59,*^ | IVCF | 40 | NR | NR | NR | NR
Rodriguez JL, 1996^59,*^ | Control | 80 | NR | NR | NR | NR
Khansarinia S, 1995^58^ ‡ | PGF | 108 | NR | 1 | 1^†^ | NR
Khansarinia S, 1995^58^ ‡ | Control | 216 | NR | NR | NR | NR

IVC = inferior vena cava; NR = not reported; PGF = Prophylactic Greenfield Filter

* gastrointestinal bleeding requiring blood transfusion: 4 patients.

† Internal jugular vein thrombosis due to the PGF insertion.

‡ Authors reported on infection as a complication, but none of the groups developed this complication.

None of the studies reported these filter related adverse events: strut fracture, misplacement, perforation and bleeding.

###### Inferior Vena Cava Filters Versus Inferior Vena Cava Filters

Two studies examined the comparative effectiveness of different kinds of filters and reported adverse events.60,61 In the study by Rosenthal et al., four patients developed groin hematomas and six patients in the Gunther Tulip group had filter misplacement at insertion.60 In the Celect arm, one patient developed a groin hematoma and another patient had filter migration. In the study by Keller et al., one patient developed filter migration, and 7 percent of the patients developed acute caval occlusion in the Gunther Tulip arm.61 In the OPTEASE arm, 3 percent of the patients developed acute caval occlusion. No filter migrations occurred in the OPTEASE arm.

##### Uncontrolled Studies

###### Strut Fracture

Seven uncontrolled studies reported on the outcome of strut fracture with IVC filters.34,65,66,70,76,79,81 These rates were uniformly low and affected fewer than 1.5 percent of filter recipients(Table 11).

Table 11 Adverse events for uncontrolled studies of inferior vena cava filters

Author, Year | Filter Complications | | | | | | | Bleeding Events, N
Author, Year | Strut Fracture, n (%) | Filter Tilt, n (%) | Filter Migration, n (%) | Filter Thrombosis, n (%) | Misplacement, n (%) | Perforation, n (%) | IVC Thrombosis/Occlusion, n (%) | Bleeding Events, N
Shang EK, 2011^113^ | NR | NR | NR | NR | NR | 1 (100%) | NR | NR
Smooth RL, 2010^108^ | NR | NR | NR | NR | NR | NR | 15 (6.6) | NR
Doody O, 2009^65^ | 1 (1.6) | NR | NR | 15 (24.6) | NR | 2 (3.3) | 1 (1.6) | NR
Phelan HA, 2009^66^ | 1 (1.5) | NR | 0 (0) | NR | NR | NR | NR | NR
Cherry RA, 2008^34^ | 2 (0.8) | 1 (0.4) | NR | NR | NR | NR | 3 (1.2) | NR
Hermsen JL, 2008^67^ | NR | NR | NR | NR | NR | 1 (1.1) | NR | NR
Mahier A, 2008^69^ | NR | NR | NR | 8 (25) | NR | NR | NR | NR
Zakhary EM, 2008^70^ | 1 (0.6) | NR | NR | NR | NR | NR | 4 (3.4) | NR
Binkert CA, 2006^71^ | NR | 8 (61.5)^*^ | 0 (0) | 0 (0) | NR | NR | NR | NR
Gonzalez RP, 2006^72^ | NR | NR | 2 (1.5) | NR | NR | NR | NR | NR
Meier C, 2006^73^ | NR | NR | 1 (2.7) | NR | NR | NR | 5 (13.5) | NR
Meier C, 2006^74^ | NR | 2 (3)^†^ | 1 (1.1) | 5 (5.3) | NR | NR | NR | NR
Rosenthal D, 2006^75^ | NR | NR | NR | 3 (2.4) | NR | NR | NR | NR
Stefanidis D, 2006^76^ | 1 (1.2) | NR | NR | NR | NR | NR | NR | NR
Rosenthal D, 2005^77^ § | NR | NR | NR | 3 (6.8)^§^ | 3 (2.9) | 3 (6.8)^§^ | NR | 3 (2.9)
Rosenthal D, 2004^79^ | 0 (0)^§^ | NR | NR | 3 (3.2) | 3 (3.2) | 0 (0)^§^ | NR | 2 (2.1)
Duperier T, 2003^80^ | NR | NR | NR | 1 (0.8) | NR | NR | 0 (0) | NR
Kurtoglu M, 2003^81^ § | 0 (0) | 0 (0) | 0 (0) | 0 (0) | 0 (0) | 0 (0) | 0 (0) | 0 (0)
Offner PJ, 2003^82^ § | NR | NR | 0 (0) | 0 (0) | NR | 0 (0) | NR | NR
Conners MS, 2002^84^ | NR | NR | 1 (0.4) | 1 (0.4) | 6 (2) | NR | 3 (1) | 1 (0.4)
Sekharan J, 2001^87^ | NR | NR | 0 (0) | 1 (0.9) | NR | NR | NR | NR
Sing RF, 2001^89^ | NR | 2 (1.3) | NR | NR | 1 (0.63) | 1 (0.6) | 1 (0.6) | 2 (1.3)
Greenfield LJ, 2000^90^ § | NR | NR | 1 (1.4) | 5 (3.5) | NR | 0 (0) | NR | 2 (0.8)^‡^
Wojcik R, 2000^91^ | NR | NR | 1 (1) | NR | NR | NR | 1 (0.95) | NR
Benjamin ME, 1999^92^ | NR | NR | NR | NR | 1 (4.3) | NR | NR | 0
Langan EM, 1999^94^ | NR | NR | NR | NR | 1 (0.5) | NR | NR | 2 (1.1)
McMurtry AL, 1999^95^ | NR | NR | NR | NR | 2 (0.8) | NR | 3 (1.2) | 0
Tola JC, 1999^96^ | NR | NR | 0 (0) | 0 (0) | 0 (0) | 0 (0) | NR | 0 (0)
Rogers FB, 1997^97^ | NR | 7 (5.5) | NR | NR | NR | NR | NR | 4 (3.0)
Sing RF98 | NR | NR | NR | NR | NR | NR | 1 (12.5) | NR
Nunn CR, 1997^99^ | NR | 1 (2.0) | 1 (2.0) | NR | NR | NR | 1 (2.0) | NR
Patton JH Jr, 1996^100^ | NR | NR | 1 (0.9) | 3 (2.7) | 3 (2.7) | NR | 1 (0.9) | 0 (0)
Leach TA, 1994^102^ | NR | 1 (0.5) | 1 (0.5) | NR | NR | NR | 0 (0) | NR
Millward SF, 1994^103^ | NR | NR | 0 (0) | 1 (33.3) | NR | NR | 0 (0) | 0 (0)
Rogers FB, 1993^104^ | NR | NR | NR | 1 (2.9) | NR | NR | NR | NR

IVC = Inferior vena cava; N = number; NR = not reported

* Mild Filter tilt in eight cases (61.5%) and more severe tilt in 2 cases 15%.

† Data for subset of patients who underwent filter retrieval.

‡ Data for overall baseline population.

§ These studies also reported on insertion-vein thrombosis and rates ranged from 0% in (Offner PJ, 2003), 2% in (Rosenthal D, 2005), 2% in (Greenfield LJ, 2000), 9% in (Kurtoglu M, 2003).

###### Filter Migration

Sixteen uncontrolled studies reported on the rare occurrence of filter migration (Table 11).66,71-74,82,84,86,87,90,91,99,100,102,103,111

###### Filter Tilt

Eight uncontrolled studies reported on the rare complication of filter tilt.34,71,74,81,89,97,99,102 One study of 132 patients with 5-year follow up data reported substantial filter tilt (> 14 degrees) among 5.5% of participants. The same study also reported strut malposition proportions as high as 38 percent.97 Another small study of 13 patients, assessing the retrievability of Bard filters at 180 days, reported a mild filter tilt (3 to 25 degrees) in eight cases (61.5%), and more severe filter tilt (greater than 10%) in two patients (15%)71 (Table 11).

###### Filter Thrombosis

Seventeen uncontrolled studies reported on the complication of filter related thrombosis.65,69,71,74,75,77,79,80 -82,84,87,90,96,100,103,104 These included the complications of insertion-site thrombosis or occlusion.82 The rates were uniformly low. The rates of insertion related thrombosis was zero in several studies71,82,96,102 and 3.1 percent at 5 years in the long term study97 (Table 11).

Our data on filter-related thrombosis should be interpreted with caution. In the primary studies, occurrence of thrombus within an IVC filter is variably reported as a device-related complication (i.e., the filter promoted thrombosis) or described as a successful use of the device (i.e, the filter did what it was supposed to do—it trapped a large embolus). The long-term impact of filter-related thrombosis is unclear—it can be entirely asymptomatic or cause significant symptoms in the legs and lower body.

###### Arterial-Venous Fistulas

Two uncontrolled studies reported on the outcome of arterial-venous fistulas79,94 with IVC filters. The percentage of patients developing fistulas ranged from 0^79^ to 0.5 percent.94

###### Filter Misplacement

Ten uncontrolled studies reported on the outcome of filter misplacement.77,79,81,84,89,92,94-96,100 The percentage of patients having filter misplacement ranged from as low as 0 percent to as high as 3.2 percent.79 96 The overall proportions were uniformly low to allow any meaningful analysis (Table 11).

###### Filter Penetration or Perforation

Ten uncontrolled studies reported on the complication of filter perforation or penetration.63,65,67,77,79,82,85,89,90,96 Five studies reported no filter perforation in any patients.79,81,82,90,96 The overall rates were uniformly low to allow any meaningful analysis. One small study reported small (<1 cm) IVC defects without contrast extravasations in three patients among 44 patients who underwent uneventful filter retrieval77(Table 11).

###### Inferior Vena Cava Thrombosis or Occlusion

Thirteen uncontrolled studies reported on the complication of IVC thrombosis or occlusion.70,73,80,84,89,91,95,98-100,102,103,108 The overall proportions were uniformly low. Two studies reported no IVC thrombosis or occlusion80,103(Table 11).

###### Bleeding

Thirteen uncontrolled studies reported on bleeding complications.77,79,81,84,89,90,92,94-97,100,103 The type of bleeding included minor bleeding, groin hematomas, and non-serious bleeding. The percentages ranged from no episodes of bleeding in several studies to rates as high as 3 percent of filter recipients.97 The overall proportions were uniformly low (Table 11).

###### Infections

Four uncontrolled studies reported on infections.79,83,87,89 Two studies reported no infections during the studies. Another study reported that 2.5 percent of patients had sepsis,83 while another study reported rates as high as 3.8 percent.89 None of these studies could distinguish whether these complications were filter related or due to the underlying risks of the severely injured trauma population.

###### Other Adverse Events

Other complications reported in a single patient included technical failure to remove IVC filter in one study,62 incorrect deployment of the IVC filter in a single patient in the operating room in another study,97 and supraventricular tachycardia in a patient during insertion in another study.72

### Proportion of Filters Retrieved

#### Randomized Controlled Trials and Controlled Observational Studies

An increasing number of temporary filters are being placed in patients with trauma to prevent PE. However there are concerns that several of these temporary filters are not retrieved in the long term placing patients at higher risk of filter related complications. Among 16 filters that were retrievable in the RCT only 2 were retrieved at 6 months.52 Retrieval rates were not consistently reported in the controlled observational studies.

##### Inferior Vena Cava Filters Versus Inferior Vena Cava Filters

In the study by Rosenthal et al., the filter retrieval rate was higher in the Celect filter arm (84 percent vs. 54 percent) compared with the Gunther Tulip filter.60 The study by Keller et al. reported the filter retrieval rate as a secondary outcome. The filter retrieval rate was higher in the OPTEASE filter group than the Gunther Tulip filter (70 percent vs. 49 percent).61

#### Uncontrolled Studies

Seventeen uncontrolled studies reported on the proportion of filters retrieved after prophylactic IVC filter placement among patients with trauma.34,62,64,65,67-71,73-79,106 There was great variability in these proportions. Although, one small cohort study of 13 patients reported clinicians retrieved all of the filters they inserted, the usual recovery rates in other cohorts were lower.71 These ranged from clinicians removing as few as one-third of the filters they inserted. Most other studies reported filter retrieval proportions that were higher.

##### Post-Thrombotic Syndrome

One uncontrolled study reported on the outcome of post-thrombotic syndrome in patients having prophylactic IVC filter placement. Among 30 patients with IVC filters, post-thrombotic syndrome occurred in 14 patients.100 Post-thrombotic syndrome is usually considered a long-term outcome related to DVT.

##### Length of Stay in the Hospital and Intensive Care Unit

Only six uncontrolled studies reported on length of stay in the hospital.74,76,83,90,91,112 The length of stay in the hospital ranged from a median duration of 28 days (range 11-139)74 to 38.5 days (range 6-118).90 Among these six studies, two studies74,90 also reported on the length of stay in the intensive care unit. The median length of stay in days in the ICU was 15.4 (range 2-93) in one study 90 while it was 15.0 (range 1–53) in the other.74

### Risk of Bias

We rated the only small RCT on this question as having a high risk of bias52 Among the controlled observational studies, only one was rated as having a moderate risk of bias and the remainder as having a high risk of bias.57

For the uncontrolled observational studies, we rated only four studies as having a moderate risk of bias and the remainder as having a high risk of bias.67,79,90,107 (Appendix E). Two included studies had severe methodological flaws including substantial differences in injury severity score and inadequate adjustment for injury severity score and concerns for potential duplication that they were ineligible for inclusion in the meta-analysis and assessment of the strength of evidence.53,54

### Strength of Evidence

All included studies which assessed the comparative effectiveness and safety of IVC Filter vs no filters were at high risk of bias, except one study at moderate risk of bias57 (Table 12).

Table 12 Body of evidence for placement of inferior vena cava filter versus no filter in the prevention of VTE in hospitalized patients with trauma

Author, Year | Outcome | Risk of Bias | Directness | Precision | Consistency | Strength of Evidence and Magnitude of Effect
| PE | High | Direct | Precise | Consistent | Low that IVC filter placement is associated with a lower incidence of PE in hospitalized patients with trauma compared with no IVC filter placement RR 0.20 (95% CI = 0.06 to 0.70; I^2^=0%)^*^
Rajesekhar, A 2011^52^ | PE | High | Direct | Imprecise | Consistent | 0% vs. 6.2%
Wilson JT, 1994^55^ | PE | High | Direct | Imprecise | Consistent | 0% vs. 7.2%
Gosin JS, 1997^56^ | PE | High | Direct | Precise | Consistent | 0% vs. 4.8%
Gorman PH, 2009^57^ | PE | Moderate | Direct | Imprecise | Consistent | 1.8% vs. 0%
Khansarinia, S 1995^58^ | PE | High | Direct | Precise | Consistent | 0% vs. 6.0%
Rodriguez JL, 1996^59^ | PE | High | Direct | Precise | Consistent | 2.5% vs. 17.5%
Author, Year | Fatal PE | High | Direct | Precise | Consistent | Low that IVC filter placement is associated with a lower incidence of fatal PE in hospitalized patients with trauma compared with no IVC filter placement RR 0.09 (0.01 to 0.81; I^2^= 0%)^*^
*Rajesekhar, A 2011^52^ | Fatal PE | High | Direct | Imprecise | Consistent | 0% vs. 0%
Wilson JT, 1994^55^ | Fatal PE | High | Direct | Imprecise | Consistent | 0% vs. 2.7%
Khansarinia, S 1995^58^ | Fatal PE | High | Direct | Precise | Consistent | 0% vs. 5.5%
Rodriguez JL, 1996^59^ | Fatal PE | High | Direct | Imprecise | Consistent | 0% vs. 10.0%
Author, Year | Mortality | High | Direct | Imprecise | Inconsistent | Insufficient that IVC filter placement is associated with less mortality in hospitalized patients with trauma compared with no IVC filter placement RR 0.70 (0.40 to 1.23; I^2^=6.7%)
*Rajesekhar, A 2011^52^ | Mortality | High | Direct | Imprecise | Inconsistent | 5.5% vs. 0%
Khansarinia, S 1995^58^ | Mortality | High | Direct | Imprecise | Inconsistent | 16.6% vs. 21.7%
Rodriguez JL, 1996^59^ | Mortality | High | Direct | Imprecise | Inconsistent | 5.0% vs. 16.2%
Author, Year | DVT | High | Direct | Imprecise | Inconsistent | Insufficient that IVC filter placement is associated with a higher incidence of DVT compared with no IVC filter placement RR 1.76 (95% CI = 0.49 to 6.18; I^2^= 56.8%):p=0.38
Rajesekhar, A 2011^52^ | DVT | High | Direct | Imprecise | Inconsistent | 5.5% vs. 0%
Rodriguez JL, 1996^59^ | DVT | High | Direct | Imprecise | | 15.0% vs. 18.7%
Gorman PH, 2009^57^ | DVT | Moderate | Direct | Precise | | 20.4% vs. 5.2%
Author, Year | Filter related thrombosis^**^ | High | Direct | Imprecise | Unknown | Insufficient to support that IVC filter placement is associated with a higher incidence of filter related thrombosis compared with no IVC filter placement
Khansarinia, S 1995^58^ | Filter related thrombosis^**^ | High | Direct | Imprecise | unknown | 1.8% vs. 0%

DVT = deep vein thrombosis; IVC = inferior vena cava; RCT = randomized controlled trial; RR = relative risk; VTE = venous thromboembolism

* No VTE-related deaths in the RCT.

** Graded on Filter related thrombosis. Data were too sparse on other complications such as filter tilt and migration to provide meaningful SOE grades on these specific complications.

We rated the strength of evidence as low to support reduction in PE and fatal PE in trauma with IVC filters compared with no filters. We based this rating on the high risk of bias, precision and consistency and directness of findings across studies. (Figure 3 and Figure 4). Our estimates for PE were robust to alternative statistical approaches, whereas the estimates for fatal PE were more fragile. Given the fragility of these findings the significant reductions in fatal PE should be viewed with caution

We rated the strength of evidence as insufficient to support a reduction in mortality in trauma with IVC filters. We based this rating on the high risk of bias, imprecision and inconsistency in the findings across studies (Figure 5). We rated the strength of evidence as insufficient to support an increase in DVT in trauma with IVC filters. We based this rating on the high risk of bias, imprecision and inconsistency in the findings across studies (Figure 6). We rated the strength of evidence as insufficient to support an increase in filter related thrombosis in trauma with IVC filters. We based this rating on the high risk of bias, precision, directness and unknown consistency in the findings from a single study.58

### Applicability

Most of these studies occurred in trauma centers and their findings would apply to severely injured trauma patients. Although most studies occurred at level 1 trauma centers, the findings might also apply to injured patients cared for in other settings with access to IVC filters. The patients in these studies were mostly severely injured as noted in their high mean/median ISS scores. The applicability of these findings to patients with less severe trauma is unknown. The proportion of men was typically higher than women, as expected in any trauma study, which may impact the generalizability of these results to female trauma patients. The studies are most directly applicable to the middle-aged adult patient population as that was the population most frequently studied, although most studies did not have any older age range cutoff. Information on racial composition was unavailable from several studies to comment on whether these findings are applicable to nonwhite patients. The definitions of standard therapy varied across studies making it difficult to determine applicability to settings where the standard therapy may be different.

## Key Question 2a What are the comparative effectiveness and safety of pharmacological and mechanical strategies to prevent venous thromboembolism in hospitalized patients with traumatic brain injury?

### Key Findings and Evidence Grades

- The strength of evidence is low that enoxaparin reduces the rates of DVT compared with no pharmacoprophylaxis in hospitalized patients with traumatic brain injury
- The strength of evidence is low that UFH reduces total mortality compared with no pharmacoprophylaxis in hospitalized patients with traumatic brain injury
- The strength of evidence is insufficient to comment on the comparative effectiveness and safety of any other pharmacological and mechanical strategies on VTE outcome and bleeding.

### Study Characteristics

Eight studies evaluated the effectiveness of pharmacological and mechanical strategies to prevent VTE in hospitalized patients with TBI.50,114-120 Most studies took place in North America.50,114,115,117-120 Two studies reported the source of funding.50,119

Of eight studies, two were a RCT50,116, five were retrospective cohort studies,114,115,117,118,120 and one was a prospective cohort study.119 Most studies recruited from the year 2000 onwards.50,114,115,116,117,118,120

Most studies enrolled patients admitted to Level 1 trauma centers,50,114,115,117,118,120 One study included patients with a Glasgow Coma Scale score less than 8^119^ and another included TBI patients with a head abbreviated injury score greater than 1^118^. One cohort excluded patients with contraindications to anticoagulants114 and the trials excluded patients with history of thromboembolism, liver disease, an INR greater than 1.5, or platelets less than 100,000 or 50,000/ uL.50,116 One cohort excluded patients requiring craniotomy118 (Table 13).

Table 13 Study, participant, and intervention characteristics for KQ 2a

Author, Year | Study Design | Intervention (Dose) | N | Mean Age Years | % Male | Mean ISS | Mean GCS | Mean AIS Head
Dudley,R.R., 2010^114^ | Retrospective cohort | Enoxaparin (30mg, sc, bd) | 128 | 47.4 | 77.3 | 31.1 | 8 | NR
Dudley,R.R., 2010^114^ | Retrospective cohort | Dalteparin (5000 U, sc, od) | 159 | 45.9 | 72.3 | 35 | 6.9 | NR
Minshall, C.T., 2011^115^ | Retrospective cohort | Enoxaparin (30mg, sc, bd) | 158 | 41.2 | 75 | 29 | NR | 3.8
Minshall, C.T., 2011^115^ | Retrospective cohort | UFH (5000 U,sc, tid) | 171 | 42 | 78 | 33.8 | NR | 4.1
Minshall, C.T., 2011^115^ | Retrospective cohort | Usual care/No Intervention | 57 | 38.3 | 69 | 30.9 | NR | 4.3
Kurtoglu,M., 2004^116^ | Randomized controlled trial | Enoxaparin (40 mg, od) | 60 | NR | NR | 19.5 | NR | NR
Kurtoglu,M., 2004^116^ | Randomized controlled trial | IPC | 60 | NR | NR | 18.3 | NR | NR
Salottolo, K., 2010^117^ | Retrospective cohort | Enoxaparin (30mg, sc, bd) | 255 | 48 | NR | NR | NR | NR
Salottolo, K., 2010^117^ | Retrospective cohort | no prophylaxis | 225 | 59.5 | NR | NR | NR | NR
Phelan, H.A., 2012 50 | Randomized controlled trial | Enoxaparin (30mg, sc, bd) | 34 | 40.7 | 64 | 17.3 | 13.5 | 3.5
Phelan, H.A., 2012 50 | Randomized controlled trial | Placebo | 28 | 42.6 | 57 | 15.7 | 13.0 | 3.1
Scudday,T., 2010^118^ | Retrospective cohort | UFH (NR) | 402 | 45.2 | 69 | 23.8 | NR | 3.4
Scudday,T., 2010^118^ | Retrospective cohort | no prophylaxis | 410 | 51.5 | 69 | 16.6 | NR | 3.4
Sadeh, Y., 2012^120^ | Retrospective cohort | Dalteparin | 93 | NR | NR | NR | NR | NR
Sadeh, Y., 2012^120^ | Retrospective cohort | No prophylaxis | 29 | NR | NR | NR | NR | NR
Gersin.K., 1992^119^ | Prospective cohort | Scd | 14 | 38.3 | 71.4 | 30.5 | 7.1 | NR
Gersin.K., 1992^119^ | Prospective cohort | no intervention | 18 | 36.1 | 77.8 | 32.1 | 6.8 | NR

AIS = Abbreviated Injury Scale; bd = twice daily; BMI = body mass index; IPC = intermittent pneumatic compression devices; ISS = Injury Severity Score; GCS = Glasgow coma scale; NR = Not reported; od= once daily; sc = subcutaneous; SCD = sequential compression devices; UFH = Unfractionated heparin

### Participant Characteristics

The number of participants in the included studies ranged from 32 to 812. Five studies reported the mean age of the participants which ranged from 36 to 47 years50,115,117-119. The majority of included participants were men (range 57 to 78 percent, respectively).50,114,115,118,119 No studies reported the race of participants. All studies but one reported the Injury Severity Score of participants on admission; the mean ranged from 15.7 to 33.8.^50,114-119^ Three studies reported the mean Glasgow Coma Scale score of participants; it ranged from 6.8 to 13.5^50,114,119^ (Table 13).

### Intervention Characteristics

#### Pharmacological Agent Versus Pharmacological Agent

One retrospective cohort study compared the effectiveness of different LMWHs (enoxaparin versus dalteparin) in preventing VTE in brain injury patients.114 Another compared the effectiveness of enoxaparin versus UFH.115 The two studies used the following doses: enoxaparin at 30 mg every 12 hours, dalteparin at 5,000 U daily, or UFH at 5,000 units three times per day (Table 13).

#### Pharmacological Agent Versus Sequential Compression Devices

The RCT compared the effectiveness of enoxaparin 40 mg daily with sequential compression devices in preventing VTE events in TBI patients116 (Table 13).

#### Pharmacological Agent Versus Control (No Pharmacoprophylaxis)

Three retrospective cohort studies and one RCT conducted in patients with brain injury evaluated the effectiveness of enoxaparin, UFH or dalteparin in preventing VTE events as compared to no treatment.50,117,118,120 The dosing schedules were 30 mg of enoxaparin or 5,000 IU of UFH administered subcutaneously every 12 hours; the dose of dalteparin used was not specified. The three cohort studies used sequential compression devices concurrently (Table 13).

#### Mechanical Agent Versus Control

One prospective cohort study of TBI patients examined the effectiveness of sequential compression devices compared with a control group in preventing VTE119 (Table 13).

### Ascertainment

Most studies did not routinely screen for VTE.50,114-116,120 One study performed weekly surveillance using duplex ultrasound examination or technetium venoscans and ventilation/perfusion scans.119 One study only routinely screened patients at high risk for VTE.118

### Outcomes

#### Venous Thromboembolism

##### Pharmacological Agent Versus Pharmacological Agent

Two studies evaluated the effectiveness of enoxaparin when compared with dalteparin and UFH respectively. One cohort study demonstrated that rates of venous thrombosis were similar in both patients treated with enoxaparin and dalteparin (7% vs. 7.5%, p=NS). 121 Similarly, the other cohort study showed that rates of deep venous thrombosis were similar in both enoxaparin and UFH groups (1% vs. 1%, p=NR) 115

##### Pharmacological Agent Versus Pharmacological Agent

Two studies evaluated the effectiveness of enoxaparin when compared with dalteparin and UFH respectively. One cohort study demonstrated that rates of venous thrombosis were similar in both patients treated with enoxaparin and dalteparin (7% vs. 7.5%, p=NS). 121 Similarly, the other cohort study showed that rates of deep venous thrombosis were similar in both enoxaparin and UFH groups (1% vs. 1%, p=NR) 115

##### Pharmacological Agent Versus Intermittent Pneumatic Compression

The single RCT demonstrated lower rates of DVT in the enoxaparin treated group as compared with the group receiving intermittent pneumatic compression (5 vs. 6.6 percent, respectively, p=0.07), whereas the rates of PE were higher in the enoxaparin group compared with the group receiving intermittent pneumatic compression (6.6 vs. 3.3 percent, respectively, p=0.04) 116(Table 14).

Table 14 Venous thromboembolic, mortality, and major bleeding outcomes in traumatic brain injury patients receiving pharmacological/mechanical prophylaxis

Author, Year | Intervention | Surveillance for VTE | N Patients | % VTE | % DVT | % PE | % Mortality | % Progression of ICH
Dudley,R.R., 2010^114^ | Enoxaparin | No | 128 | 7^*^ | NR | NR | NR | 0.08
Dudley,R.R., 2010^114^ | Dalteparin | No | 159 | 7.5^*^ | NR | 0.6 | NR | 0
Minshall, C.T., 2011^115^ | Enoxaparin | No | 158 | NR | 1 | 0^**^ | 5 | 5^**^
Minshall, C.T., 2011^115^ | UFH | No | 171 | NR | 1 | 4^**^ | 15.8 | 12^**^
Minshall, C.T., 2011^115^ | No Intervention | No | 57 | NR | 2 | 2 | 47 | NR
Kurtoglu,M., 2004^116^ | Enoxaparin | No | 60 | NR | 5^*^ | 6.6^**,†^ | 13.3 | 1.6
Kurtoglu,M., 2004^116^ | IPC | No | 60 | NR | 6.6^*^ | 3.3^**,†^ | 11.6 | 1.6
Salottolo, K., 2010^117^ | Enoxaparin | No | 255 | 3.92^*^ | NR | NR | NR | NR
Salottolo, K., 2010^117^ | no prophylaxis | No | 225 | 2.2^*^ | NR | NR | NR | 8.44
Phelan, H.A., 2012 50 | Enoxaparin | No | 34 | NR | 0 | 0 | NR | 5.9
Phelan, H.A., 2012 50 | Placebo | No | 28 | NR | 3.6 | 0 | NR | 3.6
Scudday,T., 2010^118^ | UFH | No | 402 | 1^**^ | NR | NR | 0.75 | 3^**^
Scudday,T., 2010^118^ | no prophylaxis | Yes | 410 | 3^**^ | NR | NR | 3.66 | 6^**^
Sadeh, Y., 2012^120^ | Dalteparin | No | 93 | 0 | NR | NR | NR | 0
Sadeh, Y., 2012^120^ | No prophylaxis | No | 29 | 0 | NR | NR | NR | 0
Gersin.K., 1992^119^ | Scd | Yes | 14 | 28.6^*^ | 0 | 28.6 | NR | NR
Gersin.K., 1992^119^ | no intervention | Yes | 18 | 22.2^*^ | 11.1 | 11.11 | NR | NR

DVT = deep vein thrombosis; ICH = intracranial hemorrhage; IPC = intermittent pneumatic compression devices; PE = pulmonary embolism; TBI = traumatic brain injury; UFH = unfractionated heparin; USG = ultrasonogram; V/Q= ventilation-perfusion; VTE = venous thromboembolism

* p value not significant.

** p value significant.

† Of the total PE, 6.6% in the enoxaparin arm and 3.3% in the IPC arm were fatal.

##### Any Pharmacologic Agent Versus Control (No Pharmacoprophylaxis)

Three retrospective cohort studies evaluated the effectiveness of pharmacoprophylaxis in reducing total venous thromboembolic events when compared with control; the results were highly heterogeneous.117,118,120 In one study117 the rates of VTE were higher in patients treated with enoxaparin when compared with control ( 3.92 vs. 2.2%, p=0.29) but another study demonstrated the opposite effect, rates of VTE being lower in UFH treated group (1 vs. 3% p=0.019). 118 The third study demonstrated no difference in rates of VTE between dalteparin and control groups (0% vs. 0%). 120

A RCT and cohort study assessed the rates of DVT in TBI patients treated with enoxaparin for pharmacoprophylaxis when compared with control and placebo respectively.50,115 Both studies consistently demonstrated reduced rates of DVT in patients treated with enoxaparin (1% vs 2%, p=NR; 0% vs 3.6%, p=NR).50,115 In addition to this, the cohort study also demonstrated reduced rates of DVT in patients treated with UFH when compared with control (1 vs. 2%, p=NR). 115

A cohort study showed that rates of PE were double in the UFH group compared with control (4 vs. 2 percent, respectively, p value not reported) but there no PE events in patients treated with enoxaparin. 115 However, in a RCT, patients in both enoxaparin and control groups did not experience any PE events (0 vs. 0%, p=NR) 50(Table 14).

##### Intermittent Pneumatic Compression Device Versus Control (No Prophylaxis)

One cohort study showed similar rates of total VTE in the pneumatic compression and control groups (28.6 vs. 22.2 percent, respectively, p= 0.7) but increased rates of total DVT in control groups (0 vs 11.1%, p=NR). However, the rates of PE were increased inIPC group as opposed to control (28.6 vs. 11.11 percent, respectively, p value not reported)119 (Table 14).

#### Fatal Pulmonary Embolism

##### Enoxaparin Versus Intermittent Pneumatic Compression Devices

The RCT showed increased rates of fatal PE in enoxaparin treated patients as opposed to patients treated with pneumatic compression (6.6 vs. 3.3 percent, respectively, p=0.04) 116(Table 14).

#### Mortality

##### Enoxaparin Versus Unfractionated Heparin

One study showed that total mortality was lower in the enoxaparin group as opposed to the unfractionated heparin group (5 percent versus 15.8, respectively, p<0.05)115 (Table 14).

##### Enoxaparin Versus Intermittent Pneumatic Compression

Total mortality was similar in both enoxaparin and pneumatic compression group (13.3 vs. 11.6 percent, respectively, p=0.08)116 (Table 14).

##### Pharmacological Agent Versus Control (No Pharmacoprophylaxis)

One study showed lower rate of mortality in the UFH group relative to the control group (0.75 percent versus 3.6 percent, respectively),118 and another study showed lower rates of mortality in the enoxaparin and heparin groups relative to the control group (5 percent versus 16 percent versus 47 percent, respectively, p<0.05)115 (Table 14).

### Adverse Outcomes

#### Bleeding Outcomes

##### Enoxaparin Versus Unfractionated Heparin

A cohort study showed that rates of progression of ICH were higher in heparin treated patients in comparison with enoxaparin treated patients (12% vs. 5%, p<0.05).115 Similarly, the rates of intracranial hemorrhage that required craniectomy in the two groups were 1 and 0 percent, respectively, (p<0.05). Another study reported the rates of intracranial bleeding in patients treated with enoxaparin and dalteparin (0.08 vs. 0 percent, respectively)114 (Table 14).

##### Pharmacological Agent Versus Sequential Compression Devices

A RCT showed that exacerbation of epidural hematoma occurred in 1.6 percent, respectively, in both enoxaparin and intermittent sequential compression groups.116 The rates of hematuria, injection site hematoma and bleeding from tracheostomy site were 8.3, 3.3, and 1.6 percent, in the enoxaparin group and 6.6, 0, and 0 percent in the sequential compression devices group respectively (Table 14).

##### Pharmacological Agent Versus Control (No Pharmacoprophylaxis)

A cohort study showed that rates of progression of intracranial hemorrhage were lower in the unfractionated heparin group relative to the control group (3 versus 6 percent, p=0.055)118 while a RCT showed that rates of progression of intracranial bleeding were higher in enoxaparin treated patients (5.9 vs. 3.6%). 50 The third study however showed that there was no progression of intracranial hemorrhage in both dalteparin and control groups120 (Table 14).

#### Mean Hospital Stay

##### Pharmacological Agent Versus Control

A cohort study showed that the median hospital stay was longer in the enoxaparin and unfractionated heparin groups than in the control group. (19 versus 17 versus 4 days, respectively, p<0.05)115 while a randomized controlled trial demonstrated a marginally increased length of stay in patients treated with enoxaparin compared with placebo (4.9 vs. 4.5 days).50

#### Mean Intensive Care Unit stay

##### Pharmacological Agent Versus Control

A cohort study also showed that median ICU stay was longer in the enoxaparin and unfractionated heparin groups relative to the control group (11 vs. 8 vs. 2 days respectively, p<0.05)115 while the randomized controlled trial demonstrated the opposite (2.5 vs. 3.2 days).50

##### Pharmacological Agent Versus Sequential Compression Devices

In one RCT the mean intensive care unit stay was similar in both the enoxaparin and intermittent pneumatic compression groups (10.7 vs. 10.3 days, respectively, p value not reported).116

##### Mechanical Agent Versus Control

In one study the mean ICU stay was 21.2 days in the sequential compression group and 18.4 days in the control group (p =0.5).119

#### Infections

##### Pharmacological Agent Versus SCDs

The RCT evaluated the rates of infections.116 The enoxaparin treated patients and patients treated with intermittent pneumatic compression had similar rates of infection (23.3 vs. 20 percent, respectively, P =0.07).

### Risk of Bias

We rated a cohort study as having moderate risk of bias and a randomized controlled trial to be at low risk of bias.50,114 We rated the remaining studies as high risk of bias.115-120,122,123 The RCT had biases arising from improper randomization and blinding.116 The cohort studies generally had incomplete description of the important confounders and lack of adjustment for differences between groups. They also had incomplete accounting of losses to followup. All of these are important confounders and threaten the internal validity of these studies.

### Strength of Evidence

Most of the included studies that assessed the comparative effectiveness of pharmacological and mechanical prophylaxis in hospitalized patients with traumatic brain injury were at high risk of bias. We rated the strength of evidence as low to support that enoxaparin reduced the rates of DVT compared with no pharmacoprophylaxis in hospitalized patients with traumatic brain injury based on direct, consistent evidence from a cohort study and a RCT.50,115 We also rated the strength of evidence as low to support that UFH reduced the rates of mortality compared with no pharmacoprophylaxis. We based this rating on consistent, direct and precise evidence from two cohort studies.115,118 The remainder of comparisons on the outcomes of PE, DVT, VTE and exacerbation of intracranial hemorrhage for were all rated as insufficient. This rating was based on either inconsistencies in the body of evidence, or our inability to assess consistency (Table 15).

Table 15 Body of evidence for pharmacological prophylaxis for patients with traumatic brain injury

Author, Year | Outcomes | Patients (N) | Risk of Bias | Directness | Precision | Consistency | Magnitude of Effect | Strength of Evidence
Enoxaparin vs. Dalteparin
Dudley,R.R., 2010^114^ | VTE | 287 | Moderate | Direct | Imprecise | Unknown | 7% vs. 7.5%;p=0.868 | Insufficient evidence to comment on effectiveness of enoxaparin vs. dalteparin in reducing VTE in TBI patients
Dudley,R.R., 2010^114^ | Progression of ICH | 287 | Moderate | Direct | Unknown | Unknown | 0.08% vs. 0%^*^ | Insufficient evidence to comment on effectiveness of enoxaparin vs. dalteparin in reducing progression of ICH in TBI patients
Enoxaparin vs. UFH
Minshall, C.T., 2011^115^ | DVT | 329 | High | Direct | Unknown | Unknown | 1% vs. 1%^*^ | Insufficient evidence to comment on effectiveness of enoxaparin vs. UFH in reducing DVT in TBI patients
Minshall, C.T., 2011^115^ | PE | 329 | High | Direct | Precise | Unknown | 0% vs. 4% ; p<0.05 | Insufficient evidence to comment on effectiveness of enoxaparin vs. UFH in reducing PE in TBI patients
Minshall, C.T., 2011^115^ | mortality | 329 | High | Direct | Precise | Unknown | 5% vs. 15.8%;p<0.05 | Insufficient evidence to comment on effectiveness of enoxaparin vs. UFH in reducing mortality in TBI patients
Minshall, C.T., 2011^115^ | Progression of ICH | 329 | High | Direct | Precise | Unknown | 5% vs. 12%; p<0.05 | Insufficient evidence to comment on effectiveness of enoxaparin vs. UFH in reducing progression of ICH in TBI patients
Enoxaparin vs. Control/IPC/Placebo
Salottolo, K., 2010^117^ | VTE | 480 | High | Direct | Imprecise | Unknown | 3.9% vs. 2.2%;p=0.29 | Insufficient evidence to comment on effectiveness of enoxaparin vs. IPC/control in reducing VTE in TBI patients
Salottolo, K., 2010^117^ | DVT | 397 | Moderate | Direct | Imprecise | Consistent | | Low grade evidence that enoxaparin reduces DVT in TBI patients when compared with IPC/control
Phelan, H.A., 2012 50,‡ | DVT | 62 | Low | Direct | Imprecise | Consistent | 0% vs. 3.6%, p=0.45 (Fischer's exact)
Minshall, C.T., 2011^115^ | DVT | 215 | High | Direct | Imprecise | Consistent | 1% vs. 2% *; P= ns
Kurtoglu,M., 2004^116,‡^ | DVT | 120 | High | Direct | Imprecise | Consistent | 5% vs. 6.6%; p=0.07
Kurtoglu,M., 2004^116,‡^ | PE | 397 | Moderate | Direct | Imprecise | Inconsistent | | Insufficient evidence to comment on effectiveness of enoxaparin vs. IPC/control in reducing PE in TBI patients
Phelan, H.A., 2012 50,‡ | PE | 62 | Low | Direct | Unknown | Inconsistent | 0% vs. 0%, p=NR
Kurtoglu,M., 2004^116,‡^ | PE | 120 | High | Direct | Precise | Inconsistent | 6.6% vs. 3.3%:p=0.04
Minshall, C.T., 2011^115^ | PE | 215 | High | Direct | Imprecise | Inconsistent | 0% vs. 2%: #P=0.46
Kurtoglu,M., 2004^116,‡^ | Fatal PE | 120 | High | Direct | Precise | Unknown | 6.6% vs. 3.3%;p=0.04 | Insufficient evidence to comment on effectiveness of enoxaparin vs. IPC/control in reducing Fatal PE in TBI patients
Kurtoglu,M., 2004^116,‡^ | mortality | 182 | Moderate | Direct | Imprecise | Inconsistent | | Insufficient evidence to comment on effectiveness of enoxaparin vs. IPC/control in reducing mortality in TBI patients
Phelan, H.A., 2012 50,‡ | mortality | 62 | High | Direct | Precise | Unknown | 0% vs. 0%, p=NR
Kurtoglu,M., 2004^116,‡^ | mortality | 120 | Moderate | Direct | Imprecise | Inconsistent | 13.3% vs. 11.6%;p=0.08
| Progression of intracranial hemorrhage | 182 | Moderate | Direct | Imprecise | Inconsistent | | Insufficient evidence to comment on effectiveness of enoxaparin vs. IPC/control/placebo in reducing exacerbation of epidural hematoma in TBI patients
Phelan, H.A., 2012 50,‡ | Exacerbation of epidural hematoma | 62 | Low | Direct | Imprecise | Inconsistent | 5.9 vs. 3.6%, p=0.57 (Fischer's exact)
Kurtoglu,M., 2004^116,‡^ | Progression of intracranial hemorrhage | 120 | High | Direct | Imprecise | | 1.6% vs. 1.6%^*^, p=0.75 (Fischer's exact)
UFH vs. Control
Scudday,T., 2010^118^ | VTE | 812 | High | Direct | Precise | Unknown | 1% vs. 3%;p=0.019 | Insufficient evidence to comment on effectiveness of UFH vs. control in reducing VTE in TBI patients
Minshall, C.T., 2011^115^ | DVT | 228 | High | Direct | Unknown | Unknown | 1% vs. 2% * | Insufficient evidence to comment on effectiveness of UFH vs. control in reducing DVT in TBI patients
Minshall, C.T., 2011^115^ | PE | 228 | High | Direct | Unknown | Unknown | 4% vs. 2%^*^ | Insufficient evidence to comment on effectiveness of UFH vs. control in reducing PE in TBI patients
Minshall, C.T., 2011^115^ | mortality | 1040 | High | Direct | Precise | Consistent | | Low-grade evidence that UFH reduces mortality in TBI compared with controls
Scudday,T., 2010^118^ | mortality | 812 | High | Direct | Precise | Consistent | 0.75% vs. 3.66%; P=0.007 #
Minshall, C.T., 2011^115^ | mortality | 228 | High | Direct | Precise | | 15.8% vs. 47%: p<0.05
Dalteparin vs. Control
Sadeh, Y., 2012^120^ | VTE | 122 | High | Direct | Unknown | Unknown | 0% vs. 0% | Insufficient evidence to comment on effectiveness of dalteparin vs. control in reducing total VTE in TBI patients
Sadeh, Y., 2012^120^ | Progression of ICH | 122 | High | Direct | Unknown | Unknown | 0% vs. 0% | Insufficient evidence to comment on effectiveness of dalteparin vs. control in reducing progression of ICH in TBI patients
IPC vs. Control
Gersin.K., 1992^119^ | VTE | 32 | High | Direct | Imprecise | Unknown | 28.6% vs. 22.2%: p=0.7 | Insufficient evidence to comment on effectiveness of IPC vs. control in reducing VTE in TBI patients
Gersin.K., 1992^119^ | PE | 32 | High | Direct | Unknown | Unknown | 28.6% vs. 11.1%^*^ | Insufficient evidence to comment on effectiveness of IPC vs. control in reducing PE in TBI patients

DVT = deep venous thrombosis; ICH = intracranial hemorrhage; IPC = intermittent pneumatic compression; PE = pulmonary embolism; SCD = sequential compression device; UFH = unfractionated heparin; VTE = venous thromboembolism

‡ Randomized controlled trial.

* P-values or tests of statistical significance not reported

# Two sided P-estimated using Fishers exact test.

### Applicability

The participants that these studies recruited were typical of participants admitted to other trauma centers and hence findings are generalizable. We did not have details to assess the applicability of this evidence to older subgroups and other racial groups since the studies inconsistently reported race.

## Key Question 2b What is the optimal timing of initiation and duration of pharmacologic prophylaxis to prevent venous thromboembolism in hospitalized patients with traumatic brain injury?

### Key Findings and Evidence Grades

- The strength of evidence was insufficient to comment on the effectiveness of early (< 72 hours) versus late (> 72 hours) pharmacoprophylaxis with enoxaparin, UFH or any heparin on the outcomes of VTE, DVT, PE, fatal PE, total mortality, major and minor bleeding.

### Study Characteristics

Five retrospective cohort studies assessed the optimal timing of initiation of pharmacologic prophylaxis to prevent venous thromboembolism in patients with traumatic brain injury.36,117,122-124 All studies were conducted in North America. None of the studies reported their sources of funding. All studies had recruitment dates from the year 2000 onwards. All studies included patients over 18 years of age with traumatic brain injury admitted to trauma centers. One study excluded pregnant women and patients with histories of venous thromboembolism.36 Two studies excluded patients with low platelet counts36,125 and one study excluded patients with penetrating head injuries123 (Table 16).

Table 16 Study, participants, and intervention characteristics for KQ 2b

Author, Year | Study Design | Intervention (Dose) | Timing of First Dose | N Patients | Mean Age Years | % Male | Mean ISS/GCS/AIS Head
Koehler D.M., 2011,^36^ | Retrospective cohort | Enoxaparin (30mg, sc, bd) | <=72 hrs | 268 | 39.8 | 69 | 27.8/NR/4
Koehler D.M., 2011,^36^ | Retrospective cohort | Enoxaparin (30mg, sc, bd) | >72 hrs | 401 | 40.2 | 75 | 29.4/NR/NR
Kim J., 2002,^124^ | Retrospective cohort | UFH (5000 U, sc, bd) | <72 hrs | 47 | 37.7 | NR | 30.7/9.1/NR
Kim J., 2002,^124^ | Retrospective cohort | UFH (5000 U, sc, bd) | >72 hrs | 17 | 44 | NR | 35.7/9.4/NR
Salotto K., 2011,^117^ | Retrospective cohort | Enoxaparin (30mg) | <=72 hrs | 108 | NR | NR | NR
Salotto K., 2011,^117^ | Retrospective cohort | Enoxaparin (30mg) | >72 hrs | 147 | NR | NR | NR
Reiff D.A., 2009,^122^ | Retrospective cohort | Any heparin | <24 hrs | 84 | 37.2 | 71.4 | NR
Reiff D.A., 2009,^122^ | Retrospective cohort | Any heparin (NR) | 24 to <48 hrs | 177 | 39.8 | 62.7 | NR
Reiff D.A., 2009,^122^ | Retrospective cohort | Any heparin (NR) | >48 hrs | 293 | 43 | 63.8 | NR
Depew A.J., 2008,^123^ | Retrospective cohort | Any heparin (30 mg/5000 U, sc, bd) | <72 hrs | 29 | NR | NR | NR
Depew A.J., 2008,^123^ | Retrospective cohort | Any heparin (30 mg/5000 U, sc, bd) | >72 hrs | 41 | NR | NR | NR

AIS = Abbreviated Injury Scale; bd = twice daily; BMI = Body mass index; GCS = Glasgow Coma Scale; ISS = Injury Severity Score; NR = not reported; sc = subcutaneous; UFH = unfractionated heparin

### Participant Characteristics

The numbers of participants in these studies ranged from 64 to 669. The mean age of participants was reported in three studies and ranged from 37 to 44 years.36,122,124 Only two studies reported on sex and the majority of participants were men.36,122 The mean Injury Severity Score was reported in two studies at 28.6^36^ and 33.2 respectively.124 One study reported a mean Glasgow Coma Scale score of 9.25^124^ (Table 16).

### Intervention Characteristics

All five studies evaluated the effectiveness of pharmacoprophylaxis, initiated at different times, to prevent venous thromboembolic events in hospitalized patients with traumatic brain injury.36,117,122-124 In two studies, patients were treated with only enoxaparin36,117 and in one only with UFH.124 In the remaining two studies patients were treated with either enoxaparin or UFH; the percentages of each are unknown and this treatment has been termed “any heparin.” Four studies reported the effectiveness of pharmacoprophylaxis in preventing venous thromboembolic events when initiated before 72 hours of hospitalization (early) compared with after 72 hours of hospitalization (late).36,117,123,124 Another retrospective cohort study with three arms evaluated the effectiveness of initiating pharmacologic prophylaxis before 24 hours, 24 to 48 hours, and after more than 48 hours of hospitalization.122 In three studies, sequential compression devices were placed concurrently on all patients;117,122,123 in one, pneumatic compression devices were used.124 The doses of enoxaparin and UFH used in all studies were 30 mg every 12 hours and 5000 IU daily, respectively (Table 16).

### Ascertainment

One study did weekly ultrasound examination in all patients,124 while in another only high risk patients were screened routinely with weekly duplex ultrasound examinations.123 Three studies did not screen patients for venous thromboembolic events.36,117,122

### Outcomes

#### Total venous thromboembolic events

##### Early (<72 hrs) Versus Late (>72 hrs) Pharmacoprophylaxis

A single study showed that rate of all venous thromboembolism was greater in patients who were started on enoxaparin before than 72 hrs of hospitalization (early) compared with patients in whom enoxaparin was started after 72 hours (5.56 percent versus 2.72 percent, OR 2.10, p value=0.26).117

#### Deep Vein Thrombosis

##### Early (<72 hrs) Versus Late (72 hrs) Pharmacoprophylaxis

In a different study, two out of 47 patients in an early UFH prophylaxis (<72 hours) group developed DVT compared with one out of 17 patients a late UFH prophylaxis (>72 hours) group.124 The difference was not statistically significant (p=1.00) The effectiveness of prophylaxis with any heparin initiated within 72 hours of admission as compared with later than 72 hours was reported in another cohort study, where the percentage of patients developing DVTs in the two groups were 10.4 percent and 14.6 percent respectively (p value not reported).123 In one cohort study, of the 268 patients receiving enoxaparin within 72 hours of hospitalization, one patient developed upper extremity proximal DVT and three developed lower extremity DVT.36 Of the 401 patients beginning prophylaxis after 72 hours, five patients developed upper extremity DVT and nine patients developed DVT of the lower extremity. The difference in rates of upper and lower extremity deep venous thromboses between the two groups was not statistically significant (p=0.24 and 0.28 respectively) (Table 17).

Table 17 Venous thromboembolic, mortality, and major bleeding outcomes in traumatic brain injury patients receiving early and late pharmacological prophylaxis

Author, Year | Intervention | Surveillance for VTE | N Patients | % DVT | % PE | % Mortality | % Progression of ICH
Koehler D.M., 2011,^36^ | Enoxaparin < 72hrs | No | 268 | NR | 1.5^*^ | NR | 1.46^*^
Koehler D.M., 2011,^36^ | Enoxaparin >72 hrs | No | 401 | NR | 2.2^*^ | NR | 1.54^*^
Kim J., 2002,^124^ | UFH < 72 hrs | Yes | 47 | 4.3^*^ | 4.3^*^ | 8.5^*^ | NR
Kim J., 2002,^124^ | UFH >72 hrs | Yes | 17 | 5.9^*^ | 0^*^ | 5.9^*^ | NR
Salotto K., 2011,^117^ | Enoxaparin < 72hrs | No | 108 | NR | NR | NR | 6.48^*^
Salotto K., 2011,^117^ | Enoxaparin >72 hrs | No | 147 | NR | NR | NR | 14.29^*^
Reiff D.A., 2009,^122^ | Any heparin <24 hrs | No | 84 | NR | NR | NR | NR
Reiff D.A., 2009,^122^ | Any heparin 24-48 hrs | No | 177 | NR | NR | NR | NR
Reiff D.A., 2009,^122^ | Any heparin >48 hrs | No | 293 | NR | NR | NR | NR
Depew A.J., 2008,^123^ | Any heparin <72 hrs | No | 29 | 10.4 | 3.5 | NR | 3.5
Depew A.J., 2008,^123^ | Any heparin >72 hrs | No | 41 | 14.6 | 0 | NR | 3.8

DVT = deep vein thrombosis; ICH = intracranial hemorrhage; NR = not reported; PE = pulmonary embolism; TBI = traumatic brain injury; UFH = unfractionated heparin; VTE = venous thromboembolism

* p value not significant

##### Other Timings of Initiation of Prophylaxis

Another cohort study assessed the DVT risk per 100 patients in the 3 arms. The proportion of DVT in patients with any heparin initiated before 24 hours, 24 to 48 hours and after 48 hours were 3.6/100 patients, 4.5/100 patients, 15.4/100 patients respectively. The p values are not reported122 (Table 17).

#### Pulmonary Embolism

##### Early (<72 hrs) Versus Late (72 hrs) Pharmacoprophylaxis

In one cohort, 4.3 percent of patients receiving UFH as prophylaxis within 72 hours of hospitalization developed PE as compared with none in the group that received the same prophylaxis after 72 hrs of admission (p=0.96).124 Similarly, in another cohort, 3.5% of patients receiving any heparin within 72 hours of hospital admission developed PEs while no PEs occurred in the group that received prophylaxis after 72 hours (p value not reported).123 In a third cohort, there was a higher rate of pulmonary embolism in the group receiving enoxaparin as prophylaxis within 72 hours of hospital admission compared with after 72 hours (1.5 percent versus 2.2 percent, respectively, p=0.49)36 (Table 17).

### Other Outcomes

#### Fatal PE

Of the 401 patients in one study receiving prophylaxis with enoxaparin later than 72 hours after hospitalization, 1 patient died due to pulmonary embolism.36 There were no fatal pulmonary embolic events in the group receiving the same prophylaxis within 72 hours (p value not reported).

#### Mortality

One cohort reported four deaths in a group of 47 patients receiving UFH within 72 hours of admission and one in the group of 17 patients receiving prophylaxis after 72 hours (p=1.0).124 Another cohort reported that there were no deaths due to bleeding in either the early and late prophylaxis groups.36

#### Major Bleeding

The rates of radiographic progression of intracranial hemorrhage were reported in three studies.36,117,123 In one study, the rates were similar in patients treated with enoxaparin within 72 hours of hospital admission and after 72 hours (1.46% vs. 1.54%, respectively (p=0.912).36 Similar findings were observed in another study (3.5% vs. 3.8%, p value not reported).123 Only one study showed that rates of progression of intracranial hemorrhage were lower in the group receiving enoxaparin prophylaxis earlier rather than later (6.48 percent versus 14.3 percent, p=0.92)117 (Table 17).

#### Minor Bleeding

Two studies reported rates of minor bleeding events. According to one study, the rates of hematuria in patients treated with UFH within 72 hours of hospital admission and after 72 hours were six percent (p=1.00).124 Another study reported that none of the patients developed any non-cranial bleeding complications from enoxaparin prophylaxis.36

### Risk of Bias

All five included studies were at high risk of bias. The studies had biases arising from incomplete description of principal confounders and their adjustment and improper accounting of losses to follow-up.

### Strength of Evidence

All of the included studies that assessed the comparative effectiveness of early versus late pharmacoprophylaxis in hospitalized patients with traumatic brain injury were at high risk of bias. We rated the strength of evidence as insufficient for all comparisons and outcomes. We based this rating on either inconsistencies in the body of evidence, or our inability to assess consistency (consistency unknown) in a single study (Table 18).

Table 18 Body of evidence for timing of pharmacological prophylaxis for patients with traumatic brain injury

Author, Year | Outcomes | Risk of Bias | Directness | Precision | Consistency | Magnitude of Effect
Enoxaparin <72 hrs vs. >72 hrs
| VTE | High | Direct | Imprecise | Unknown | Insufficient evidence to comment on effectiveness of enoxaparin started <72 hrs vs. >72 hrs in reducing VTE in TBI patients
Salotto K., 2011^117^ | | High | Direct | Imprecise | Unknown | 5.6% vs. 2.7%;p=0.26
| DVT | High | Direct | Imprecise | Unknown | Insufficient evidence to comment on effectiveness of enoxaparin started <72 hrs vs. >72 hrs in reducing DVT in TBI patients
Koehler D.M., 2011^36^ | | High | Direct | Imprecise | Unknown | 1.5% vs. 3.5%;p= 0.12
| PE | High | Direct | Imprecise | Unknown | Insufficient evidence to comment on effectiveness of enoxaparin started <72 hrs vs. >72 hrs in reducing PE in TBI patients
Koehler D.M., 2011^36^ | | High | Direct | Imprecise | Unknown | 1.5% vs. 2.2%; p=0.49
| Fatal PE | High | Direct | Unknown | Unknown | Insufficient evidence to comment on effectiveness of enoxaparin started <72 hrs vs. >72 hrs in reducing fatal PE in TBI patients
Koehler D.M., 2011^36^ | | High | Direct | Unknown | Unknown | 0% vs. 0.3%^*^
| Progression of ICH | High | Direct | Imprecise | Inconsistent | Insufficient evidence to comment on effectiveness of enoxaparin started <72 hrs vs. >72 hrs in reducing progression of ICH in TBI patients
Koehler D.M., 2011^36^ | | High | Direct | Imprecise | Inconsistent | 1.5% vs. 1.5%; p=0.912
Salotto K.,2011^117^ | | High | Direct | Imprecise | Inconsistent | 6.5% vs. 14.3%; p=0.92
UFH <72 hrs vs. >72 hrs
| DVT | High | Direct | Imprecise | Unknown | Insufficient evidence to comment on effectiveness of UFH started <72 hrs vs. >72 hrs in reducing DVT in TBI patients
Kim J., 2002^124^ | | High | Direct | Imprecise | Unknown | 4.3% vs. 5.9%;p=1.00
| PE | High | Direct | Imprecise | Unknown | Insufficient evidence to comment on effectiveness of UFH started <72 hrs vs. >72 hrs in reducing PE in TBI patients
Kim J., 2002^124^ | | High | Direct | Imprecise | Unknown | 4.3% vs. 0%; p=0.96
| Mortality | High | Direct | Imprecise | Unknown | Insufficient evidence to comment on effectiveness of UFH started <72 hrs vs. >72 hrs in reducing total mortality in TBI patients
Kim J., 2002^124^ | | High | Direct | Imprecise | Unknown | 8.5% vs. 5.9%; p=1.00
Any Heparin <72 hrs vs. >72 hrs
| DVT | High | Direct | unknown | Unknown | Insufficient evidence to comment on effectiveness of any heparin started <72 hrs vs. >72 hrs in reducing DVT in TBI patients
Depew A.J., 2008^123^ | | High | Direct | Unknown | Unknown | 10.4% vs. 14.6%^*^
| PE | High | Direct | unknown | Unknown | Insufficient evidence to comment on effectiveness of any heparin started <72 hrs vs. >72 hrs in reducing PE in TBI patients
Depew A.J., 2008^123^ | | High | Direct | Unknown | Unknown | 3.5% vs. 0%^*^
| Progression of ICH | High | Direct | Unknown | Unknown | Insufficient evidence to comment on effectiveness of any heparin started <72 hrs vs. >72 hrs in reducing progression of ICH in TBI patients
Depew A.J., 2008^123^ | | High | Direct | Unknown | Unknown | 3.5% vs. 3.8%

DVT = deep venous thrombosis; ICH = intracranial hemorrhage; PE = pulmonary embolism; TBI = traumatic brain injury; UFH = unfractionated heparin

# There were no randomized controlled trials.

* Tests of statistical significance between groups or P values unavailable.

### Applicability

The studies were generally representative of patients with traumatic brain injury in the United States. Gender was inconsistently reported thus we could not assess the applicability of these findings to females. Some studies excluded patients with previous VTE as well as those at higher risk of bleeding such as those with low platelet counts limiting generalizability to these high risk subgroups.

## Key Question 3 What are the comparative effectiveness and safety of pharmacologic and mechanical strategies to prevent venous thromboembolism in hospitalized patients with burns?

### Key Points and Evidence Grades

- The strength of evidence was insufficient to comment on the comparative effectiveness and safety of pharmacologic and mechanical strategies to prevent VTE in hospitalized patients with burns.

### Study Characteristics

We identified only one small cohort study of 20 patients that reported on PE prophylaxis with IVC filters for patients with burns.126 This was a single center study in an academic medical center's burn unit conducted over a period of 2 years. The study follow up was up to 1 year after hospital discharge.

### Participant Characteristics

The investigators placed IVC filters in 20 patients with acute burns at high risk for PE. These risk factors included prolonged immobilization due to ventilator dependence, old age, size of burn, site of burns, previous history of VTE, and contraindications against use of anticoagulants. The investigators placed five filters due to preexisting VTE and the remaining 15 filters for PE prophylaxis. The study required Doppler imaging prior to filter placement to exclude DVT. Among the 15 patients who underwent insertion of filters strictly for prophylaxis there were nine men and six women. Of these, the mean age was 38.9 years, with a range of 22 to 69 years. Burn size ranged from 15 to 79 percent total body surface area (mean, 37.8 percent).

### Intervention Characteristics

Vascular surgeons placed Venatech titanium bird's nest filters; 18 were placed with femoral access and two with right jugular percutaneous access. Filter insertions happened from 1 to 75 days after the burn incident. The patients received no other VTE preventative therapies.

### Outcomes

#### Deep Vein Thrombosis/Pulmonary Embolism

There were no PEs in any patient after filter insertion.

#### Mortality

Data on mortality among the 15 who received filters for prophylaxis were unavailable. However, nine of the 20 enrolled patients died.

#### Adverse Events

The study reported no significant bleeding, IVC thromboses, or filter related complications.

### Risk of Bias

The study received a high risk of bias rating due to methodologic limitations in design and reporting, sample size, and the absence of a control group to allow any meaningful conclusions.

### Strength of Evidence

The strength of evidence was insufficient to comment on the comparative effectiveness and safety of pharmacologic and mechanical strategies to prevent VTE in hospitalized patients with burns. We based this rating on the high risk of bias and unknown consistency from a single study.

### Applicability

This was a single center study at an academic burn center and the participants were similar to those at other academic burn centers. The study did not report racial composition of participants. However the overall small sample size of the study limits generalizability.

## Key Question 4 What are the comparative effectiveness and safety of pharmacologic and mechanical strategies to prevent VTE in hospitalized patients with liver disease?

We found no studies that directly address the comparative effectiveness and safety of pharmacologic strategies among patients with liver disease.

## Key Question 5 What are the comparative effectiveness and safety of pharmacologic and mechanical strategies to prevent VTE in hospitalized patients receiving antiplatelet therapy?

### Key Points and Evidence Grades

- The strength of evidence is insufficient to comment on differences in rates of major bleeding comparing prophylactic rivaroxaban with enoxaparin in patients concomitantly treated with antiplatelet agents.
- The strength of evidence is insufficient to comment on differences in rates of major bleeding comparing prophylactic dabigatran with enoxaparin in patients concomitantly treated with aspirin.

### Study Characteristics

We found two studies, with very similar research methods using pooled data from large phase III trials that report on the safety of pharmacologic VTE prophylaxis on patients who are concomitantly on anti-platelet agents. The study by Eriksson performed a pre-specified analysis of pooled data from four major phase III trials of the RECORD program 127 and reported on the safety of concomitant use of non-steroidal anti-inflammatory drugs and platelet function inhibitors including aspirin in patients receiving pharmacologic VTE prophylaxis. The RECORD trial was a double-dummy design where over 12,000 patients undergoing elective total knee replacement or total hip replacement were randomized to receive either oral Rivaroxaban or subcutaneous enoxaparin.

Friedman et al performed a post hoc analysis of the bleeding risk in patients who received pharmacologic prophylaxis while concomitantly on NSAIDs and ASA using pooled data from three pivotal trials: RE-MODEL, RE-NOVATE, and RE-MOBILIZE. 128 All trials were prospective, double-blind, double dummy, randomized and multicenter and used a non-inferiority design; they compared 220mg and 150mg dabigatran etexilate once daily with 40 mg enoxaparin subcutaneously in patients undergoing knee arthroplasty and total hip arthroplasty (Table 19).

Table 19 Study and participant characteristics for KQ 5

Author, Year | Study Design | Arm, n | Age (Years) Mean | Male (%) | Weight (kg)Mean
Eriksson B.I, 2012^127^ | Pooled data from 4 trials (RECORD 1-4). | Arm 1 (Rivaroxaban), 563 | 68 | 47 | 82
Eriksson B.I, 2012^127^ | Pooled data from 4 trials (RECORD 1-4). | Arm 2 (Enoxaparin/placebo), 526 | 68 | 47 | 83
Friedman,R.J, 2012^128^ | Pooled data from 3 trials (RE-MODEL, RE-NOVATE, RE-MOBILIZE) | Arm 1 (220 mg Dabigatran, no ASA), 1149 | 66.1 | NR | NR
Friedman,R.J, 2012^128^ | Pooled data from 3 trials (RE-MODEL, RE-NOVATE, RE-MOBILIZE) | Arm 2 (150 mg Dabigatran, no ASA), 1149 | 65.4 | NR | NR
Friedman,R.J, 2012^128^ | Pooled data from 3 trials (RE-MODEL, RE-NOVATE, RE-MOBILIZE) | Arm 3 (Enoxaparin, no ASA), 1167 | 66.1 | NR | NR
Friedman,R.J, 2012^128^ | Pooled data from 3 trials (RE-MODEL, RE-NOVATE, RE-MOBILIZE) | Arm 4 (220 mg Dabigatran + ASA), 126 | 65.5 | NR | NR
Friedman,R.J, 2012^128^ | Pooled data from 3 trials (RE-MODEL, RE-NOVATE, RE-MOBILIZE) | Arm 5 (150 mg Dabigatran + ASA), 128 | 65.1 | NR | NR
Friedman,R.J, 2012^128^ | Pooled data from 3 trials (RE-MODEL, RE-NOVATE, RE-MOBILIZE) | Arm 6 (Enoxaparin+ ASA), 132 | 65.6 | NR | NR

Kg = kilograms; n = number; NR = not reported; VTE = venous thromboembolism

### Participant Characteristics

In the Eriksson study there were 6,093 patients in the Rivaroxaban arm and 6,107 patients in the enoxaparin or placebo arm. In both arms the mean age was 68 years and 47 percent of the participants were male. The mean weight was 82 kg in the Rivaroxaban arm and 83 kg in the enoxaparin arm. Nine percent of patients from each arm (563 in rivaroxaban; 526 in enoxaparin) concomitantly used PFIs or ASA at least once during the at-risk period (defined as starting at day 1 of surgery and ending up to 2 days after the last intake of the study medication).

In the Friedman study out of the total 8,135 patients, 4,405 (54.1%) were on concomitant NSAIDs and 386 (4.7%) were on concomitant ASA. The baseline characteristics of those on ASA as compared with the rest of the groups were similar. The percentage of females in all groups ranged 57.8%-60.9%, the mean age ranged between 65.1±10.3 to 66.1±10.0 years and the average BMI ranged 29.2±5.7 to 29.6±5.5.

### Intervention Characteristics

In the Eriksson study, in a double-dummy design, patients were randomized to receive either oral Rivaroxaban 10mg once daily starting 6 to 8 hours after surgery or subcutaneous enoxaparin 40 mg daily starting 12 hours before surgery (RECORD 1-3) or enoxaparin 30mg twice daily starting 12 to 24 hours after wound closure or adequate hemostasis was achieved (RECORD 4). Patients undergoing total hip arthroplasty received oral Rivaroxaban for 31–39 days or subcutaneous enoxaparin for 31–39 days or enoxaparin (RECORD 1) or enoxaparin for 10–14 days with placebo tablets for 31–39 days (RECORD 2); patients undergoing total knee arthroplasty (RECORD 3 and 4) received Rivaroxaban or enoxaparin for 10–14 days. The co-medications investigated in this pre-specified analysis were NSAIDs and PFIs or ASA. There was no limitation on the choice of a specific drug or dose of NSAIDs, PFIs or ASA in the study protocol.

In the Friedman study, the RE-MODEL and RENOVATE trials were performed in Europe and compared 220 mg and 150 mg dabigatran etexilate once daily with 40 mg enoxaparin (in patients undergoing knee arthroplasty-RE-MODEL; total hip arthroplasty-RE-NOVATE). The RE-MOBILIZE trial compared 220 mg or 150 mg once daily dabigatran etexilate with 30 mg enoxaparin twice daily in patients undergoing knee arthroplasty (Table 20).

Table 20 Intervention characteristics for KQ 5

Author, Year | Arm Name | Drug Name | Dose, Route, Frequency of Anticoagulant | Timing of First Dose | Concurrent Therapy
Eriksson B.I, 2012^127^ | Rivaroxaban | Rivaroxaban | 10mg, Oral, od | 6-8 hours after surgery | PFI or ASA
Eriksson B.I, 2012^127^ | Enoxaparin/placebo | Enoxaparin/placebo | 40mg, SC, od | 12 hours before surgery | PFI or ASA
Eriksson B.I, 2012^127^ | Enoxaparin/placebo | Enoxaparin/placebo | 30mg, SC, bid | 12-24 hours after wound closure or after adequate hemostasis was obtained | PFI or ASA
Eriksson B.I, 2012^127^ | Enoxaparin/placebo | Enoxaparin/placebo | 40mg, SC, od | 12 hours before surgery | PFI or ASA
Eriksson B.I, 2012^127^ | Enoxaparin/placebo | Enoxaparin/placebo | 30mg, SC, bid | 12-24 hours after wound closure or after adequate hemostasis was obtained | PFI or ASA
Friedman,R.J, 2012^128^ | Arm 1 (220 mg Dabigatran, no ASA), 1149 | Dabigatran | 220mg, Oral, Daily | 1-4/6-12 hours after surgery | None
Friedman,R.J, 2012^128^ | Arm 2 (150 mg Dabigatran, no ASA), 1149 | Dabigatran | 150mg, Oral, Daily | 1-4/6-12 hours after surgery | None
Friedman,R.J, 2012^128^ | Arm 3 (Enoxaparin, no ASA), 1167 | Enoxaparin | 40mg, SC, od 30mg, SC, bid | 6-12 hours after surgery | None
Friedman,R.J, 2012^128^ | Arm 4 (220 mg Dabigatran + ASA), 126 | Dabigatran | 220mg, Oral, Daily | 1-4/6-12 hours after surgery | ASA
Friedman,R.J, 2012^128^ | Arm 5 (150 mg Dabigatran + ASA), 128 | Dabigatran | 150mg, Oral, Daily | 1-4/6-12 hours after surgery | ASA
Friedman,R.J, 2012^128^ | Arm 6 (Enoxaparin+ ASA), 132 | Enoxaparin | 40mg, SC, od 30mg, SC, bid | 6-12 hours after surgery | ASA

ASA = acetylsalicyclic acid; NR = not reported; PFI = platelet function inhibitors; SC = subcutaneous; VTE = venous thromboembolism

### Outcomes

#### Rivaroxaban Versus Enoxaparin

The only endpoints evaluated in the Eriksson study were the composite major and minor clinically relevant bleeding and any bleeding occurring after first post-operative oral study drug intake (rivaroxaban or matching placebo tablet). These events were recorded during the at-risk period (from day of surgery, which is day 1, to the last intake of study drug or until the onset of event, whichever came first). The authors looked at three time periods: day 1–3; day 4–7 and after day 7 based on the consideration that the use of co-medications may vary over time and the relative risk of bleeding decreases over time after surgery. The relative bleeding rates were calculated for each time period as well as for the entire at-risk period and expressed as rates per 100 patient-weeks.

The relative bleeding rates for use versus non-use of PFIs or ASA with rivaroxaban and enoxaparin remained relatively constant and were similar between rivaroxaban and enoxaparin groups over the three at-risk time intervals. Over the total at-risk period, the number of patients concomitantly on PFIs or ASA who had any bleeding events were 3.6% for the rivaroxaban group (20/563) and 3.25% for the enoxaparin group (17/526) with a corresponding relative rate ratios of 1.32 in the rivaroxaban group (95% CI 0.85-2.05) and 1.40 in the enoxaparin/placebo group (95%CI 0.87-2.25). The number of patients who had the composite of major and non-major clinically relevant bleeding were 1.4% for the rivaroxaban group (98/563) and 1.0% for the enoxaparin group (5/526) with a relative rate ratio of 1.11 (95% CI 0.55-2.55) and 1.13 (95% CI 0.47-2.75) for rivaroxaban and enoxaparin respectively (Tables 21 and 22).

Table 21 Outcomes (any bleeding) for KQ 5 over the total at-risk period

Author, Year | Arm, n | Number of Patients With Co-Medications | Outcome | n (%) of Patients With Outcomes | Rate per 100 Patient-Weeks With Co-Medication | Rate per 100 Patient-Weeks Without Co-Medication | Measures of Association, Rate Ratio* for Use vs. Non-use (95% CI)
Eriksson B.I, 2012^127^ | Rivaroxaban, 6093 | 563 | Any Bleeding | 20 (3.6) | 2.04 (1.25-3.15) | 1.76 (1.58-1.95) | 1.32 (0.85-2.05)
Eriksson B.I, 2012^127^ | Enoxaparin/placebo, 6107 | 526 | Any Bleeding | 17 (3.2) | 2.06 (1.20-3.29) | 1.63 (1.46-1.81) | 1.40 (0.87-2.25)

CI = confidence interval

Table 22 Outcomes (major bleeding) for KQ 5 over the total at-risk period

Author, Year | Arm Name, n | N for Analysis | Outcome | Patients With Outcome, n (%)
Eriksson B.I, 2012^127^ | Rivaroxaban, 6093 | 563 (with co-medication-PFI/ASA) | Major and non-major clinically relevant bleeding | 8 (1.4)
Eriksson B.I, 2012^127^ | Enoxaparin/placebo, 6107 | 526 (with co-medication-PFI/ASA) | Major and non-major clinically relevant bleeding | 5 (1.0)
Friedman,R.J, 2012^128^ | Arm 1 (220 mg Dabigatran, no ASA), 1149 | 1149 | Major bleeding | 16 (1.4)
Friedman,R.J, 2012^128^ | Arm 2 (150 mg Dabigatran, no ASA), 1149 | 1149 | Major bleeding | 11 (1.0)
Friedman,R.J, 2012^128^ | Arm 3 (Enoxaparin, no ASA), 1167 | 1167 | Major bleeding | 14 (1.2)
Friedman,R.J, 2012^128^ | Arm 4 (220 mg Dabigatran + ASA), 126 | 126 | Major bleeding | 2 (1.6)
Friedman,R.J, 2012^128^ | Arm 5 (150 mg Dabigatran + ASA), 128 | 128 | Major bleeding | 2 (1.6)
Friedman,R.J, 2012^128^ | Arm 6 (Enoxaparin+ ASA), 132 | 132 | Major bleeding | 4 (3.0)

ASA = acetylsalicyclic acid; NR = not reported; PFI=platelet function inhibitors; SC = subcutaneous; VTE = venous thromboembolism

#### Dabigatran Versus Enoxaparin

In the Friedman study, the reported outcome was major bleeding events defined as clinically overt bleeds associated with transfusion of 2 or more units of packed red cells, symptomatic retroperitoneal, intracranial, intraocular or intraspinal bleeding or bleeding that leads to surgery. The percentage of major bleeding events for dabigatran 220mg, with and without concomitant ASA (<160mg/day) were 1.6% and 1.4% (OR 1.14; CI 0.26-5.03), P=0.862respectively. The percentage of bleeding events for enoxaparin with and without concomitant ASA were 3.0% and 1.2% (OR 2.57; CI 0.83-7.94), P=0.101 as compared with concomitant ASA of 1.6% for both 220mg and 150mg of dabigatran. For both NSAIDs and ASA the authors did not find a significant difference in bleeding between patients with and without concomitant therapy in any treatment arm and there was no significant difference in major bleeding events between dabigatran and enoxaparin within co-medication subgroups (Table 22).

### Risk of Bias

Both the Eriksson and Friedman studies were rated as low risk of bias because both were pre-specified explorative subgroup analyses of large randomized trials.

### Strength of Evidence

The strength of evidence is insufficient to comment on differences in rates of major bleeding comparing prophylactic rivaroxaban with enoxaparin in patients concomitantly treated with antiplatelet agents. We based this rating on a single trial with low risk of bias, imprecise findings and unknown consistency.

The strength of evidence is insufficient to comment on differences in rates of major bleeding comparing prophylactic dabigatran with enoxaparin in patients concomitantly treated with aspirin. This rating was based on results from a RCT with low risk of bias, imprecise findings and unknown consistency (Table 23).

Table 23 Body of evidence for pharmacologic prophylaxis for venous thromboembolism among patients on antiplatelet agents

Author, Year | Outcomes | Risk of Bias | Directness | Precision | Consistency | Magnitude of Effect
Rivaroxaban vs. enoxaparin | | | | | | Insufficient evidence to comment on difference in rates of major bleeding with prophylactic rivaroxaban or enoxaparin in patients concomitantly treated with antiplatelet agents
Eriksson B.I, 2012^127^ | Major bleeding | Low | Direct | Imprecise | unknown | 3.6% vs. 3.25%^*^
Dabigatran vs. enoxaparin * | | | | | | Insufficient evidence to comment on difference in rates of major bleeding with prophylactic dabigatran or enoxaparin in patients concomitantly treated with aspirin
Friedman,R.J, 2012^128^ | Major bleeding^‡^ | Low | Direct | Imprecise | unknown | 1.6% vs. 3.0%, Risk ratio 0.68 (95% C.I. 0.22 to 2.1) *

* Data presented for 150 mg dose of dabigatran.

‡ The major bleeding events are defined as fatal bleeds; clinically overt bleeds in excess of what was expected and either associated with a ≥20g/l reduction in hemoglobin or leading to transfusion of two or more units of packed cells or whole blood; symptomatic retroperitoneal, intracranial, intraocular or intraspinal bleeding; bleeding requiring treatment cessation; bleeding leading to reoperation; and surgical site bleeds.

### Applicability

The findings of this study might be applicable to patients who are undergoing total hip arthroplasty or total knee arthroplasty who will need VTE prophylaxis while continuing to be on ASA.

## Key Question 6 What are the comparative effectiveness and safety of pharmacologic and mechanical strategies to prevent venous thromboembolism in hospitalized patients undergoing bariatric surgery?

### Key Points and Evidence Grades

In hospitalized patients having bariatric surgery:

- The strength of evidence is low that prophylactic inferior vena cava filters do not decrease the risk of PE relative to no filter use, in patients also receiving non-invasive mechanical measures.
- The strength of evidence is low that prophylactic inferior vena cava filters increase the risk of all-cause death relative to no filter use, in patients also receiving non-invasive mechanical measures.
- The strength of evidence is insufficient that prophylactic inferior vena cava filters increase the risk of post-operative DVT relative to no filter use, in patients also receiving non-invasive mechanical measures and pharmacological prophylaxis.
- The strength of evidence is insufficient that prophylactic inferior vena cava filters decrease the risk of fatal PE relative to no filter use, in patients also receiving non-invasive mechanical measures.
- The strength of evidence is insufficient to support the comparative effectiveness and safety of any pharmacological strategies

### Study Characteristics

We identified 21 articles that reported on VTE prevention strategies in hospitalized patients undergoing bariatric surgery. There were no RCTs addressing this KQ; all included studies were observational cohort studies. We also identified two case reports (1 patient each) that described filter complications in bariatric surgery patients. Six studies reported prospective data collection,129-134 and one other reported that a portion of the data were collected prospectively.135 The remaining studies were retrospective cohorts.131,135,136-146,149 or case reports of filter complications.147,148 All studies took place in the United States; only three enrolled patients from multiple centers136,143,149 (Table 24 and Table 25).

Table 24 Characteristics of studies of IVC filters among patients undergoing bariatric surgery

Author, Year | Design | Arm | N | Mean Age, Years | Male,% | Body Mass Index, kg/m^2^
Controlled Observational Studies
Birkmeyer, N. J., 2010^149^ | Retrospective Cohort | Filter | 542 | NR | 30 | >50 in 72%
Birkmeyer, N. J., 2010^149^ | Retrospective Cohort | No filter | 5834 | NR | 19 | >50 in 34%
Gargiulo, N.J., 2006^135^ | Retrospective-Prospective | Filter | 58 | NR | 41.3 | >55 in 100%
Gargiulo, N.J., 2006^135^ | Retrospective-Prospective | No filter | 351 | NR | 41.3 | >55 in 12%
Li, W., 2012^136^ | Retrospective Cohort | Filter | 322 | 47 | 31.4 | 45.3
Li, W., 2012^136^ | Retrospective Cohort | No Filter | 96806 | 46 | 21.1 | 44.5
Obeid, F. N., 2007^138^ | Retrospective Cohort | Filter | 246 | 46.6 | 23.6 | 60
Obeid, F. N., 2007^138^ | Retrospective Cohort | No filter | 1847 | 44.7 | 14 | 48.8
Overby, D. W., 2009^139^ | Retrospective Cohort | Filter | 160 | NR | 14.55 | 51.42
Overby, D. W., 2009^139^ | Retrospective Cohort | No filter | 170 | NR | 14.55 | 51.42
Uncontrolled Observational Studies
Kardys, C. M. 2008^137^ | Retrospective Cohort | Filter | 31 | 42 | NR | 71.2
Piano, G., 2007^134^ | Prospective Cohort | Filter | 59 | 43 | 17 | 61
Schuster, R., 2007^140^ | Retrospective Cohort | Filter | 24 | 49.8 | 58.3 | >50 in 88%
Van Ha, T. G., 2011^142^ | Retrospective Cohort | Filter | 9 | 45 | 60 | >50
Vaziri, K., 2010^141^ | Retrospective Cohort | Filter | 41 | 48 | 29 | 58.4
Case Reports of Filter Complications
Schweitzer, M., 2006^147^ | Case report | Filter | 1 | 63 | Female | 45
Veerapong J., 2008^148^ | Case report | Filter | 1 | 31 | Male | 74

BMI = body mass index; N = number; NR = not reported

Table 25 Characteristics of studies of pharmacologic comparisons among patients undergoing bariatric surgery

Author, Year | Design | Intervention and Comparator | N Patients | Mean Age Years | %Male | BMI(kg/m^2^)
Borkgren-Okonek, M. 2008^129^ | Prospective Cohort | Enoxaparin 40mg sq q12, SCD, ambulation and preop heparin sq, BMI ≤50 and qd for 10 days post discharge (A) | 124 | 44.7 | 22.6 | 44.9
Borkgren-Okonek, M. 2008^129^ | Prospective Cohort | Enoxaparin 60mg sq q12, SCD, ambulation and preop heparin sq, BMI >50 and qd for 10 days post discharge (A) | 99 | 44.3 | 27.3 | 57.4
Hamad, G.G., 2005^143^ | Retrospective Cohort | Enoxaparin 40mg sq q12 (A) | 180 | 39.7 | 3 | 46
Hamad, G.G., 2005^143^ | Retrospective Cohort | Enoxaparin 40mg sq qd (S)- post op for 12-120 hours | 84 | 47.5 | 29 | 56.8
Hamad, G.G., 2005^143^ | Retrospective Cohort | Enoxaparin 40mg sq qd (S)-post op for 12-24 hours | 180 | 41.9 | 10 | 49.9
Hamad, G.G., 2005^143^ | Retrospective Cohort | Enoxaparin 30mg sq qd (R)-pre op | 100 | 39.5 | 25 | 47
Hamad, G.G., 2005^143^ | Retrospective Cohort | Enoxaparin 30mg sq qd (R)-post discharge | 124 | 42.1 | 18 | 51.5
Kothari, S. 2007^130^ | Prospective Cohort | Enoxaparin 40mg sq q12 and SCD, ambulation (A) | 238 | 42 | NR | 48.7
Kothari, S. 2007^130^ | Prospective Cohort | Heparin sq 5000iu q8hrs and SCD, ambulation (S) | 238 | 44 | NR | 47
Ojo, P., 2008^144^ | Retrospective Cohort | Enoxaparin 40mg sq q12 (S) | 59 | 48 | 33.9 | 57
Ojo, P., 2008^144^ | Retrospective Cohort | Enoxaparin 60mg sq q12 (A) | 68 | 46 | 61.8 | 58
Raftopoulos, I., 2008^131^ | Prospective Cohort | Enoxaparin 30mg sq q12 extended for 10days post d/c (S) | 176 | 44.1 | 18.75 | 46.1
Raftopoulos, I., 2008^131^ | Prospective Cohort | Enoxaparin 30mg sq q12 during hospital stay, SCD (S) | 132 | 42.6 | 15.2 | 47.8
Rowan, BO., 2008^132^ | Prospective Cohort | Enoxaparin 40mg sq q12, SCD and ambulation (A) | 33 | 40.8 | 18 | 48.5
Rowan, BO., 2008^132^ | Prospective Cohort | Enoxaparin 30mg sq q12, SCD and ambulation (S) | 19 | 41.7 | 26 | 48.4
Scholten, D. J., 2002^145^ | Retrospective Cohort | Enoxaparin 40mg sq q12, SCD and ambulation (A) | 389 | 44.3 | 15.8 | 50.4
Scholten, D. J., 2002^145^ | Retrospective Cohort | Enoxaparin 30mg sq q12 and SCD, ambulation (S) | 92 | 43.7 | 20.2 | 51.7
Simone, E. 2008^133^ | Prospective Cohort | Enoxaparin 40mg sq q12 (A) | 24 | 40 | 12.5 | 48.8
Singh, K., 2011^146^ | Retrospective Cohort | Enoxaparin 40mg sq q12, ambulation for BMI 41-49 (A) | 145 | 43 | 53 | 48
Singh, K., 2011^146^ | Retrospective Cohort | Enoxaparin 50mg sq q12, ambulation for BMI 50-59 (A) | 9 | 43 | 53 | 51
Singh, K., 2011^146^ | Retrospective Cohort | Enoxaparin 60mg sq q12, ambulation for BMI > 60 (A) | 5 | 43 | 53 | 65
Singh, K., 2011^146^ | Retrospective Cohort | Enoxaparin 30mg sq q12, ambulation for BMI < 40 (S) | 11 | 43 | 53 | 39

A = Augmented dose; BMI = body mass index; iu = International Units; NR = not reported; qd = once daily; q12 = once every 12 hours; R = reduced dose, S = Standard dose given for VTE prophylaxis; SCD = sequential compression devices; sq = subcutaneous

# Studies measured Serum Factor Xa- levels.

### Participant Characteristics

Patients underwent a variety of surgical procedures including: Roux-en-Y gastric bypass (both open and laparoscopic, but predominantly laparoscopic), sleeve gastrectomy, adjustable laparoscopic gastric banding, and biliary-pancreatic diversion. Patient characteristics were generally consistent across studies. All studies included both men and women, and the mean age of participants, when reported, ranged from 39.5 to 49.8 years. Most studies reported mean Body Mass Index (BMI) which ranged from 45 to 71 kg/m^2^. Most studies did not explicitly describe the prevalence of a prior history of VTE. The duration of followup was generally 2 to 6 weeks, however one study reported a mean follow-up of 262 days137 and another study reported follow-up of greater than 2 years.146

Among the 12 studies that reported on filters,134-142,147 -149 five included control groups of patients undergoing bariatric surgery who did not receive filters.135,136,138,139,149 Two of these were multicenter, observational studies of patients included in large clinical registries.136,149 Five studies reported on uncontrolled cohorts of patients who underwent filter placement.134,137,140,141,142 Studies size ranged from one patient (case reports of filter complications) to 97,128 patients (registry study).136 The uncontrolled cohorts ranged in size from nine patients142 to 59 patients.134 The smallest of these cohorts focused on patients undergoing bilateral common iliac vein filter placement (rather than IVC filter placement) in patients with unusually large inferior vena cava diameters.142 Two studies were case reports of single bariatric surgical patients who had filter-related complications.147,148 The studies on pharmacologic prophylaxis ranged in size from 40 patients133 to 668 patients.143

Patient and hospitalization characteristics varied by treatment allocation in studies that compared interventions. For the more intensive prophylaxis, the studies appeared to target patients at higher risk of thrombosis. In the registry studies by Birkmeyer et al149and Li et al,136 patients with filters tended to have lower baseline mobility, be male, and have a prior history of VTE. Li et al136 also noted that patients receiving filters more frequently had sleep disordered breathing and pulmonary hypertension. In the study by Kardys et al.,137 clinicians preferentially placed filters in patients with a history of prior VTE, a known hypercoagulable state or a history of profound immobility, or who were morbidly obese (having a mean BMI of 71.2 kg/m^2^). Overby et al. offered filters to patients with elevated levels of coagulation markers, impaired mobility, severe sleep apnea or hypoventilation, prior VTE, and more severe obesity.139 Obeid et al. also preferentially placed filters in the most obese patients, and those with prior VTE; they also placed significantly more filters in men than in women.138 In the study by Gargiulo et al.,135 investigators preferentially placed filters in patients with BMI greater than 55 kg/m^2^.

Similarly, clinicians appeared to use different pharmacological regimens depending on the severity of obesity, or according to practice patterns at the study center that related to patient risk for thrombosis. Consequently, different prophylactic regimens tended to be associated with the type of surgery (laparoscopic vs. open), the duration of surgery, or the length of hospital stay. Of the four studies of pharmacological prophylaxis that used enoxaparin doses of 60 mg twice daily,129,133,144,146 two did so only in the most obese patients (with BMIs of >59 kg/ m^2^, average BMI of 65^146^ or >50 kg/ m^2^, average BMI of 57.4^129^). In the one study that compared unfractionated heparin with enoxaparin,130 BMI was slightly but significantly higher in enoxaparin-treated patients (48.7 vs. 47 kg/m^2^, p = 0.04), and mean operative time was more than 30 minutes longer in the unfractionated heparin-treated patients (130 vs. 160 minutes, p< 0.001). In the single study of prolonged pharmacological prophylaxis versus inpatient prophylaxis alone, the 132 patients who underwent surgery between 2003 and 2005 received 30 mg twice daily of enoxaparin subcutaneously starting 1 hour prior to surgery and continued through hospitalization, which averaged 3.0 days in duration. A second group of 176 patients who underwent surgery in 2006 and 2007, received enoxaparin starting 12 hours postoperatively, and continued throughout hospitalization (averaging 2.2 days in duration) and for a 10-day period following discharge. In addition to the significantly shorter length-of-stay in the second group, patients in this group had fewer open procedures (0 versus 4 patients) and fewer conversions to open procedures after failed laparoscopic interventions (0 versus 5 patients).131

### Intervention Characteristics

#### Inferior Vena Cava Filters

Of the 12 studies of filters, 11 studies evaluated IVC filters,134-141,147,148,149 and one studied bilateral common iliac vein filters.142 The types of filters varied according to physician practice and preference. Filters included the retrievable Gunther Tulip^®^, Bard Recovery^®^, OptEase^®^, Cook Celect^®^, Bard G2^®^; as well as filters that are not generally intended for retrieval including Greenfield stainless steel, Simon Nitinol^®^, and Cordis TRAPEASE^®^ filters. The large registry studies by Birkmeyer et al. and Li et al did not report on the specific filter types.136,149 Six studies of filter prophylaxis described concurrent use of both mechanical prophylaxis with sequential compression devices and pharmacotherapy (enoxaparin, heparin, or warfarin).134,135,137-139,147 Two described the use of filters with concurrent heparin or low molecular weight heparin prophylaxis only.141,148 Only one of the controlled studies reported filter retrieval rates,139 however all four of the uncontrolled cohort studies that used retrievable filters reported filter retrieval rates,134,140-142 which ranged from 68 to 100 percent. There were no studies comparing different types of IVC filters head-to-head.

#### Pharmacologic Prophylaxis

Studies of pharmacologic prophylaxis involved patients receiving at least two different regimens based on our inclusion criteria. All studies used active drug therapy in all patients, rather than comparisons with placebo or no prophylaxis. Enoxaparin and unfractionated heparin were the only specific drugs studied. Seven studies employed varying doses of enoxaparin,129,132,133,143-146, two of which used weight-based dosing.129,146 In the one study that included patients receiving either enoxaparin or unfractionated heparin,130 one group of patients received enoxaparin 40 mg subcutaneously twice daily and group received unfractionated heparin 5,000 units subcutaneously every 8 hours. In one study, all patients received enoxaparin 30 mg subcutaneously twice daily, but the timing of initiation and duration of prophylaxis differed between the two comparison groups.131 The dosing regimens of enoxaparin were: 30 mg once daily143 or twice daily,131,132,145,146, 40 mg once daily143 or twice daily,129,130,133,143-146 50 mg twice daily,146 and 60 mg twice daily.129,133,144,146

#### Dose of Pharmacotherapy

We categorized doses as “standard” prophylactic dosing (enoxaparin 30 mg twice daily or 40 mg once daily and heparin 5,000 units every 8 hours) or “augmented” dosing, including enoxaparin 40 mg, 50 mg, and 60 mg twice daily. According to this classification, four studies included groups of patients receiving standard versus augmented dosing,132,143,145,146 and three studies compared two or more augmented dosing regimens.129,144,146 One of these studies also included patients who received reduced dosing (30 mg once daily).143 Each of the four studies that included two or more augmented dosing regimens included a group receiving 40 mg twice daily and a group receiving 60 mg twice daily.129,133,144,146

#### Timing of Pharmacotherapy

Four studies initiated pharmacotherapy prior to surgery,130,131,145,146 and four studies initiated pharmacotherapy after surgery;129,132,133,144 the timing was variable in the five-center study by Hamad et al.143 The planned duration of pharmacotherapy was for the hospital stay in three studies;130,131,133 until “fully ambulatory” or hospital discharge in one study;145 for 2 weeks postoperatively in one study;144 for 10 days following discharge in one study;129 was not clearly specified in one study;146 and varied by center in the multicenter study by Hamad et al., ranging from 2 to 10 days.143 In the pharmacokinetic study by Rowan et al. that compared two different doses of enoxaparin, the study assessed anti-Xa level after the first and third doses of the drug, so the total duration of prophylaxis was neither relevant to the results, nor reported.132 Some studies described concurrent mechanical prophylactic interventions, including pneumatic compression devices in six studies129-132,145,146 and early ambulation in four.129,132,145,146 None of the included studies indicated that other non-pharmacologic prophylactic measures were delivered to only one treatment arm and not the other.

#### Ascertainment of Thrombotic Outcomes

Most studies relied on clinically diagnosed (symptomatic) thrombosis, and did not employ routine surveillance for VTE prior to hospital discharge. However, three studies reported using ultrasound and/or computed tomographic venography prior to filter removal.134,139,142 and one study reported performing bilateral lower extremity ultrasound prior to hospital discharge.131

### Outcomes

#### Pulmonary Embolism

##### Inferior Vena Cava Filter Versus No Inferior Vena Cava Filter

In the study by Gargiulo et al.,135 no perioperative PEs occurred in the 58 patients with filters (0 percent), whereas the nine of the 351 patients without filters suffered from PE (2.6 percent), of whom five died (1.4 percent). There were no multivariable adjustments for differences between groups. Obeid et al. compared 1,847 patients who did not get filters with 246 patients who did.138 Perioperative PE occurred in 11 of those who did not get filters (0.59 percent) and two of those with filter (0.8 percent). In the study by Overby et al.,139 there were five PEs identified in the 170 patients who did not receive filters (2.9 percent), and one in the 160 patients who did (0.63 percent). Li et al. found a higher rate of PE among the 322 patients with filters (0.31%) than in 96,806 without filters (0.12%), P = 0.33.^136^ No authors adjusted for potential confounders in their analyses.

##### Uncontrolled Studies of Inferior Vena Cava Filters

In the uncontrolled cohort studies, perioperative PE rates ranged from 0 to 6.5 percent.137

##### VTE Outcomes (Pulmonary Embolism and/or Deep Vein Thrombosis)

###### Low-Molecular Weight Heparin Versus Unfractionated Heparin

In the study by Kothari et al. that compared enoxaparin 40 mg subcutaneously twice daily with unfractionated heparin 5,000 units every 8 hours, a single PE occurred in the heparin-treated patients (0.42 percent), with no thrombotic events in the enoxaparin-treated patients within 30 days of surgery130 (Table 28).

Table 28 VTE outcomes among bariatric surgery patients undergoing pharmacological prophylaxis

Author, Year | Design | Arm | N Patients | VTE Diagnosis | Perioperative Pulmonary Embolism, n(%) | Perioperative DVT, n(%)
Borkgren-Okonek, M. 2008^129^ | Prospective Cohort | Enoxaparin 40mg sq q12, SCD, ambulation and preop Heparin sq, BMI ≤50 and qd for 10 days post discharge | 124 | US, CTA, VQ scan | 1(0.8) | 1(0.8)
Borkgren-Okonek, M. 2008^129^ | Prospective Cohort | Enoxaparin 60mg sq q12, SCD, ambulation and preop Heparin sq, BMI >50 and qd for 10 days post discharge | 99 | US, CTA, VQ scan | NR | NR
Hamad, G.G., 2005^143^ | Retrospective Cohort | Enoxaparin 40mg sq q12(A) | 180 | NR | 1(0.6) | 0(0)
Hamad, G.G., 2005^143^ | Retrospective Cohort | Enoxaparin 40mg sq qd (S) post op for 12-120 hours | 84 | NR | 1(1) | 0(0)
Hamad, G.G., 2005^143^ | Retrospective Cohort | Enoxaparin 40mg sq qd(S) post op for 12-24 hours | 180 | NR | 0(0) | 0(0)
Hamad, G.G., 2005^143^ | Retrospective Cohort | Enoxaparin 30mg sq qd(R)pre op | 100 | NR | 2(2) | 0(0)
Hamad, G.G., 2005^143^ | Retrospective Cohort | Enoxaparin 30mg sq qd(R)post discharge | 124 | NR | 2(1.6) | 1(0.8)
Kothari, S. 2007^130^ | Prospective Cohort | Enoxaparin 40mg sq q12 and SCD, ambulation | 238 | NR | 0(0) | 0(0)
Kothari, S. 2007^130^ | Prospective Cohort | Heparin sq 5000u q8hrs and SCD, ambulation | 238 | NR | 1(0.42) | 0 (0)
Ojo, P., 2008^144^ | Retrospective Cohort | Enoxaparin 40mg sq q12 | 59 | NR | NR | NR
Ojo, P., 2008^144^ | Retrospective Cohort | Enoxaparin 60mg sq q12 | 68 | NR | NR | NR
Raftopoulos, I., 2008^131^ † | Prospective Cohort | Enoxaparin 30mg sq q12, SCD extended for 10days post d/c | 176 | Doppler US prior to d/c, chest CT | 0(0) | 0(0)
Raftopoulos, I., 2008^131^ † | Prospective Cohort | Enoxaparin 30mg sq q12, SCD during hospital stay, SCD | 132 | Doppler US prior to d/c, chest CT | 3(2.3) | 3(2.3)
Scholten, D. J., 2002^145^ ‡ | Retrospective Cohort | Enoxaparin 40mg sq q12, SCD and ambulation (A) | 389 | NR | 0(0) | 2(0.5)
Scholten, D. J., 2002^145^ ‡ | Retrospective Cohort | Enoxaparin 30mg sq q12 and SCD, ambulation (S) | 92 | NR | 4 (4.3) | 1 (1.1)
Simone, E. 2008^133^ | Prospective Cohort | Enoxaparin 40mg sq q12 | 24 | NR | NR | NR
Simone, E. 2008^133^ | Prospective Cohort | Enoxaparin 60mg sq q12 | 16 | NR | NR | NR
Singh, K., 2011^146^ | Retrospective Cohort | Enoxaparin 40mg sq q12, SCD, ambulation for BMI 41-49(A) | 145 | Doppler US, CT Angio | 0 (0) | 0 (0)
Singh, K., 2011^146^ | Retrospective Cohort | Enoxaparin 50mg sq q12, SCD, ambulation for BMI 50-59 (A) | 9 | Doppler US, CT Angio | 0 (0) | 0 (0)
Singh, K., 2011^146^ | Retrospective Cohort | Enoxaparin 60mg sq q12, SCD, ambulation for BMI > 60 (A) | 5 | Doppler US, CT Angio | 0 (0) | 0 (0)
Singh, K., 2011^146^ | Retrospective Cohort | Enoxaparin 30mg sq q12, SCD, ambulation for BMI < 40 (S) | 11 | Doppler US, CT Angio | 0 (0) | 0 (0)

A = Augmented dose; LMWH = low molecular weight heparin; NR = not reported; q12 = once every 12 hours; qd = once daily; R = reduced dose; S = standard dose given for VTE prophylaxis sq = subcutaneous; UF = unfractionated heparin

† Raftopoulos, I., 2008^131^ also reported statistically significant difference on VTE outcomes between extended duration vs enoxaparin group, 6 vs 0 or 4.5% vs 0 %; P=0.006.

‡ Scholten, D. J., 2002^145^ also reported on statistically significant difference on VTE outcomes between Standard dose and Augment dose, 5 vs 2 or 5.4% vs 0.5%, P<0.01.

###### Enoxaparin Versus Extended-duration Enoxaparin

In the study by Raftopoulos et al, thrombotic events occurred in six of the 132 patients in the short-term prophylaxis group (4.5 percent) and none of the 176 in the extended-prophylaxis group (p= 0.006).131Three of the thrombotic events were DVTs and three were PEs. This difference remained statistically significant after excluding from the analysis patients who required conversion to open procedures (p = 0.03) (Table 28-see footnote).

###### Enoxaparin at Standard Versus Augmented Dosing

Three studies reported on VTE outcomes in patients receiving standard versus augmented enoxaparin dosing.143,145,146 In the study by Scholten et al., among 92 patients receiving enoxaparin 30 mg twice daily (standard dosing) there were five thrombotic events (5.4 percent), including four PEs (4.3 percent) and one DVT (1.1 percent).145 In this same study, among 389 patients who received 40 mg twice daily (augmented) there were two thrombotic events (0.5 percent), both DVTs. In the study by Singh et al.,146 none of the 11 patients receiving standard dose enoxaparin (30 mg twice daily) had thrombotic events. Similarly, none of the 159 patients who received augmented dosing (ranging from 40 mg to 60 mg every 12 hours according to weight) had thrombotic events. Hamad et al. found one patient of 264 (0.4 percent) with a PE with standard dosing of 40 mg once daily, and one patient of 180 (0.6 percent) with a PE in the augmented treatment group dosed with 40 mg twice daily.143 There were no DVTs described in either arm (Table 28).

###### Enoxaparin at Standard Versus Reduced Dosing

In the five-center study by Hamad et al., two of the centers used enoxaparin at 30 mg once daily (reduced dosing, 224 patients), and two other centers used 40 mg once daily (standard dosing, 264 patients).143 The study reported thrombotic events in five patients (2.2 percent) receiving 30 mg once daily (4 PEs [1.8 percent] and 1 DVT [0.4 percent]). There was one PE in a patient receiving 40 mg once daily (0.4 percent) (Table 28).

###### Differing Augmented Enoxaparin Dosing Regimens, 40 mg Twice Daily Versus 50 or 60 mg Twice Daily

In the study by Borkgren-Okonen et al., among the 124 patients receiving 40 mg twice daily, there were two thrombotic events (1.6 percent) (1 PE [0.8 percent] and 1 DVT [0.8 percent]).129 Among the 99 patients receiving 60 mg twice daily, there were no thrombotic events. Singh et al. reported no thrombotic events among the 145 patients receiving 40 mg twice daily and no events among the five patients receiving 60 mg twice daily.146 Additionally, no patients of the nine receiving 50 mg twice daily developed thrombosis. Ojo et al.144 and Simone et al.133 did not report on thrombotic outcomes (Table 28).

#### Deep Vein Thrombosis

##### Inferior Vena Cava Filter Versus No Inferior Vena Cava Filter

Obeid et al. reported perioperative DVT in 12 (0.65 percent) patients not receiving filters and three (1.2 percent) of those who did.138 Overby et al. reported DVT in four patients without filters (2.4 percent) and five patients with filters (3.1 percent).139 In the registry study by Li et al., DVT occurred in 0.93% of patients with filters compared with 0.12% of those without (P < 0.001).136

##### Uncontrolled Studies of Inferior Vena Cava Filters

In the uncontrolled cohort studies of IVC filters, perioperative DVT rates ranged from 0 percent134,141,142 to 21 percent (5 of 24 patients)140 (Table 26).

Table 26 VTE outcomes among patients undergoing bariatric surgery who received inferior vena cava filters

Study | Design | Arm | N Patients | Device Type | VTE Diagnosis | Pulmonary Embolism, n (%) | DVT (Including Device-Related DVT), n (%) | Total Mortality, n (%)
IVC Filter vs. No IVC Filter
Birkmeyer, N. J., 2010^149,†^ | Retrospective Cohort | Filter | 542 | Filter | A physician diagnosis of DVT or PE | NR | NR | 10(1.85)
Birkmeyer, N. J., 2010^149,†^ | Retrospective Cohort | No filter | 5834 | No filter | A physician diagnosis of DVT or PE | NR | NR | 30(0.51)
Gargiulo, N.J., 2006^135^ | Retrospective-Prospective | Filter | 58 | Trapease, Simon-Nitinol, Greenfield, Bard Recovery | NR | 0(0) | 2(3) | 0(0)^#^
Gargiulo, N.J., 2006^135^ | Retrospective-Prospective | No filter, | 351 | No filter | NR | 9(2.56) | NR | 5(1.42)^#^
Li, W., 2012^136^ | Retrospective Cohort | Filter | 322 | NR | NR | 1(0.31) | 3(0.93) | 1(0.31)
Li, W., 2012^136^ | Retrospective Cohort | No Filter | 96806 | No Filter | NR | 116(0.12) | 116(0.12) | 29(0.03)
Obeid, F. N., 2007^138^ | Retrospective Cohort | Filter | 246 | NR | NR | 2 (0.8) | 3(1.2) | 2(0.81)
Obeid, F. N., 2007^138^ | Retrospective Cohort | No filter | 1847 | No filter | NR | 11 (0.59) | 12 (0.65) | 4(0.22)
Overby, D. W., 2009^139^ | Retrospective Cohort | Filter | 160 | Celect, Gunther Tulip, Bard Recovery, Optease, Venatech, Bard G2 | CT Venography or Doppler US | 1(0.63) | 5(3.13) | 3(0.9)
Overby, D. W., 2009^139^ | Retrospective Cohort | No filter | 170 | No filter | CT Venography or Doppler US | 5(2.94) | 4(2.35) | 3(0.9)
Uncontrolled Studies of IVC Filter
Kardys, C. M. 2008^137^ | Retrospective Cohort | Filter | 31 | Greenfield Stainless Steel^®^ | NR | 2 (6.4) | 1(3.1) | 2(6.4)
Piano, G., 2007^134^ | Prospective Cohort | Filter | 59 | Gunther Tulip^®^ | Doppler US | 1 (1.69) | 0 (0) | 0(0)
Schuster, R., 2007^140^ | Retrospective Cohort | Filter | 24 | Gunther Tulip^®^ | NR | 1(4.2) | 5 (21.0) | 0(0)
Van H, T. G., 2011^142^ | Retrospective Cohort | Filter (Iliac vein) | 10 | Gunther Tulip, Celect | Doppler US, Venogram | 0(0) | 0(0) | 0(0)
Vaziri, K., 2010^141^ | Retrospective Cohort | Filter | 41 | Gunther Tulip^®^, G2^®^ filters | NR | 0(0) | 2 (4.9) | 1(2.4)

DVT = deep vein thrombosis; N = number; NR= not reported; PE = pulmonary embolism; VTE = venous thromboembolism

# Authors reported PE related mortality.

† Authors reported composite VTE outcomes only: Filter group: 11(2.03); No Filter group: 31(0.53).

#### Composite Outcomes

##### Inferior Vena Cava Filter Versus No Inferior Vena Cava Filter

Birkmeyer et al.,149 found that patients treated at hospitals that used filters in over 10 percent of their bariatric surgery patients had a significantly higher risk of perioperative VTE (PE and DVT combined) than patients treated at hospitals with less liberal use of filters [OR 1.6 (95 % C.I. 1.2 to 2.0).] The data did not allow for assessment of individual endpoints such as PE or mortality (Table 26). The odds ratio for death or permanent disability associated with filter placement was 2.4 (95% C.I. 0.99 to 6.3) after adjustment for the likelihood of receiving a filter. In the same study, after adjustment for differences between groups, IVC filter use was not statistically significantly associated with VTE or major complications.149 However there was a trend toward more “serious complications” (including reoperation, renal failure, and other complications associated with risk of death or disability) in patients receiving filters [OR: 1.4 (95% confidence interval, 0.91 to 2.2)].

##### Mortality

###### Inferior Vena Cava Filter Versus No Inferior Vena Cava Filter

Obeid et al. reported two patients with filters died (0.81 percent) and four patients who did not receive filters died (0.22 percent).138 In the study by Gargiulo et al. there with no fatalities in the 58 patients with filters and five fatal PEs among the 351 patients who did not receive filters (1.4 percent)135 (Table 26). Death from PE or indeterminate causes occurred in 0.31% of those with filters and in 0.03% of those without filters (P = 0.003) in the registry study by Li et al.136 As noted above (in Composite Outcomes) in the study by Birkmeyer et al.,149 the odds ratio for death or permanent disability associated with filter placement was 2.4 (95% C.I. 0.99 to 6.3) after adjustment for the likelihood of receiving a filter.

###### Uncontrolled Studies of Inferior Vena Cava Filters

Three of these uncontrolled cohorts reported all-cause perioperative mortality rates of 0 percent,134 2.4 percent,141 and 6.5 percent137 (Table 26).

###### Low-Molecular Weight Heparin Versus Unfractionated Heparin

There were no deaths in either group in the study by Kothari et al. that compared unfractionated heparin with enoxaparin130(Table 29).

Table 29 Safety profile of pharmacological interventions to prevent VTE in bariatric surgical patients

Author, Year | Arm | N Patients | Bleeding Requiring PRBC, n (%) | Bleeding Requiring Surgery, n (%) | Minor Bleeding, n (%) | Total Peri Operative Mortality, n (%)
Enoxaparin vs. Unfractionated Heparin
Kothari, S. 2007^130^ | Enoxaparin 40mg sq q12 and SCD, ambulation | 238 | 14(5.9) | 4(1.7) | NR | 0(0)
Kothari, S. 2007^130^ | Heparin sq 5000u q8hrs and SCD, ambulation | 238 | 3(1.3) | 0(0) | NR | 0(0)
Enoxaparin vs. Extended-Duration Enoxaparin
Raftopoulos, I., 2008^131^ | Enoxaparin 30mg sq q12 extended for 10days post d/c | 176 | 0(0) | 1(0.56) | NR | 0(0)
Raftopoulos, I., 2008^131^ | Enoxaparin 30mg sq q12 during hospital stay, SCD | 132 | 6(4.5) | 1(0.75) | NR | 0(0)
Enoxaparin at Standard vs. Augmented Dosing
Hamad, G.G., 2005^143^ | Enoxaparin 40mg sq q12(A) | 180 | 3(1.7) | NR | NR | NR
Hamad, G.G., 2005^143^ | Enoxaparin 40mg sq qd(S) post op for 12-120 hours | 84 | 0(0) | NR | NR | NR
Hamad, G.G., 2005^143^ | Enoxaparin 40mg sq qd(S) post op for 12-24 hours | 180 | 3(1.7) | NR | NR | NR
Hamad, G.G., 2005^143^ | Enoxaparin 30mg sq qd(R) pre op | 100 | 0(0) | NR | NR | NR
Hamad, G.G., 2005^143^ | Enoxaparin 30mg sq qd(R) post discharge | 124 | 1(0.8) | NR | NR | 2(1.6)
Scholten, D. J., 2002^145^ | Enoxaparin 40mg sq q12, SCD and ambulation(A) | 389 | NR | 1(0.26) | NR | NR
Scholten, D. J., 2002^145^ | Enoxaparin 30mg sq q12 and SCD, ambulation(S) | 92 | 1(1.1) | NR | NR | NR
Singh, K., 2011^146^ | Enoxaparin 40mg sq q12, ambulation for BMI 41-49(A) | 145 | 4(2.8) | 1(0.7) | NR | NR
Singh, K., 2011^146^ | Enoxaparin 50mg sq q12, ambulation for BMI 50-59(A) | 9 | 0(0) | 0(0) | NR | NR
Singh, K., 2011^146^ | Enoxaparin 60mg sq q12, ambulation for BMI > 60(A) | 5 | 1(20) | 0(0) | NR | NR
Singh, K., 2011^146^ | Enoxaparin 30mg sq q12, ambulation for BMI < 40(S) | 11 | 0(0) | 0(0) | NR | NR
Differing Augmented Enoxaparin Dosing Regimens
Borkgren-Okonek, M. 2008^129^ | Enoxaparin 40mg sq q12, SCD, ambulation and preop heparin sq, BMI ≤50 and qd for 10 days post discharge | 124 | 4(3.2) | 1(0.8) | NR | 0(0)
Borkgren-Okonek, M. 2008^129^ | Enoxaparin 60mg sq q12, SCD, ambulation and preop heparin sq, BMI >50 and qd for 10 days post discharge | 99 | 1(1) | 0(0) | NR | 1(1)
Ojo, P., 2008^144^ | Enoxaparin 40mg sq q12 | 59 | 0(0) | NR | NR | NR
Ojo, P., 2008^144^ | Enoxaparin 60mg sq q12 | 68 | 0(0) | NR | NR | NR
Simone, E. 2008^133^ | Enoxaparin 40mg sq q12 | 24 | 1(4.2) | NR | NR | NR
Simone, E. 2008^133^ | Enoxaparin 60mg sq q12 | 16 | 0(0) | NR | NR | NR
Singh, K., 2011^146^ | Enoxaparin 40mg sq q12, ambulation for BMI 41-49(A) | 145 | 4(2.8) | 1(0.7) | NR | NR
Singh, K., 2011^146^ | Enoxaparin 50mg sq q12, ambulation for BMI 50-59(A) | 9 | 0(0) | 0(0) | NR | NR
Singh, K., 2011^146^ | Enoxaparin 60mg sq q12, ambulation for BMI > 60(A) | 5 | 1(20) | 0(0) | NR | NR
Singh, K., 2011^146^ | Enoxaparin 30mg sq q12, ambulation for BMI < 40(S) | 11 | 0(0) | 0(0) | NR | NR

A = augmented dose; n = number; NR = not reported; PRBC = PPI plus bismuth subsalicylate, rifabutin, and ciprofloxacin; R = reduced dose; S = standard dose given for VTE prophylaxis

# Authors describe serious hemorrhage as that occurring within 30 days of surgery and requiring >4 units blood products or reoperation.

###### Enoxaparin Versus Extended-Duration Enoxaparin

There were no perioperative deaths in this study130 (Table 29).

###### Enoxaparin at Standard Versus Augmented Dosing

None of the three studies reported any perioperative deaths among patients receiving standard or augmented enoxaparin dosing143,145,146 (Table 29).

###### Enoxaparin at Standard Versus Reduced Dosing

Two of the patients receiving reduced dosing of enoxaparin died (0.9 percent) compared with none of those receiving standard dosing in a single study143 (Table 29).

###### Differing Augmented Enoxaparin Dosing Regimens, 40 mg Twice Daily Versus 50 or 60 mg Twice Daily

Only one study reported on mortality. Borkgren-Okonek et al. reported one death in a patient receiving 60 mg twice daily (0.4 percent) and no deaths among the patients receiving 40 mg twice daily. The study attributed the fatality to respiratory failure and prolonged post-operative mechanical ventilation in a patient with a BMI of 82 and did not attribute it to VTE or bleeding129 (Table 29).

#### Filter Complications

The cohort studies (both controlled and uncontrolled) reported adverse events including: filter migration to the heart (one patient),149 nonfatal IVC thrombosis (one patient),140 fatal IVC thrombosis (one patient),149 errant placement of the filter into the common iliac vein (one patient),141 wrong positioning of the filter (two patients),137 pneumothorax (one patient),139 hemopericardium (one patient),139 and the inability to perform a transvenous ablation of a cardiac accessory pathway due to the filter (one patient).139

Among the case reports of unexpected filter complications, in one case the filter migrated to the right ventricle and was successfully removed percutaneously via a transjugular approach.148 The second report attributed a patient death to an occlusive thrombus at the site of the IVC filter occurring 2 weeks postoperatively.147 Additional autopsy findings included a small rent in the IVC with a small retroperitoneal hematoma, thought to be not large enough to have caused the patient's death. The authors postulated that an acute decrease in cardiac filling due to acute IVC occlusion was responsible for this patient's hemodynamic collapse (Table 27).

Table 27 Filter retrieval rates and device complications in bariatric surgery patients who received inferior vena cava filters

Author, Year | Arm | N Patients | Device Type | Filter Retrieval Rate n ( %) | Device Complications, Other n (%)
Controlled Observational Studies
Birkmeyer, N. J., 2010^149^ | Filter | 542 | NR | NR | 2^†^
Birkmeyer, N. J., 2010^149^ | No filter | 5834 | no filter | NR | NA
Gargiulo, N.J., 2006^135^ | Filter | 58 | Multiple | NR | 3(5.17)Ω
Gargiulo, N.J., 2006^135^ | No filter | 351 | no filter | NA | NA
Li, W., 2012^136^ | Filter | 322 | NR | NR | NR
Li, W., 2012^136^ | No filter | 96806 | No filter | NR | NA
Obeid, F. N., 2007^138^ | Filter | 246 | NR | NR | NR
Obeid, F. N., 2007^138^ | No filter | 1847 | no filter | NR | NA
Overby, D. W., 2009^139^ | Filter | 160 | Multiple | 147(92%) | 4(2.5)^§^
Overby, D. W., 2009^139^ | No filter | 170 | no filter | NR | NA
Uncontrolled Observational Studies
Kardys, C. M. 2008^137^ | Filter | 31 | Greenfield Stainless Steel^®^ | NR | 2(6.4)β
Piano, G., 2007^134^ | Filter | 59 | Gunther Tulip^®^ | 52(88) | NR
Schuster, R., 2007^140^ | Filter | 24 | Gunther Tulip^®^ | 20(83) | NR
Van H, T. G., 2011^142^ | Filter (Iliac vein) | 10 | Gunther Tulip, Celect | 10(100) | NR
Vaziri, K., 2010^141^ | Filter | 41 | Gunther Tulip^®^, G2^®^ filters | 28(68) | 2(4.87)α
Case Reports
Schweitzer, M., 2006^147^ | Case report | 1 | Optease | NA | 1(100)^#^
Veerapong J., 2008^148^ | Case report | 1 | Gunther-Tulip | 1(100 | 1(100)δ

IVC = inferior vena cava; n = number; NA = not applicable; NR = not reported

† The complications included fatal IVC thrombosis and IVC filter migration to the heart.

§ The complications were due to insertion (pneumothorax), early removal (hemopericardium, pulmonary embolism) and delayed removal (unable to perform transvenous accessory pathway ablation) of the IVC filter.

Ω 1 postoperative IVC thrombosis occurred 4 months after Trapease IVC filter placement while 2 postoperative localized, insertion-site DVTs occurred 3 months after filter placement.

α 1 patient had self-limiting pain at the insertion site of the IVC filter for 5 days while the other patient had a filter deployed in the right common iliac vein.

β The complication was malposition of the IVC filter in the 2 patients.

# The IVC filter was completely occluded by a thrombus in this patient.

δ The IVC filter migrated to the right ventricle in this patient.

#### Bleeding

##### Low-Molecular-Weight Heparin Versus Unfractionated Heparin

In the study by Kothari et al, bleeding events requiring transfusion occurred in 14 patients (5.9 percent) treated with enoxaparin and three patients (1.3 percent) receiving heparin (p= 0.01).130 Reoperation for bleeding was required in four patients in the enoxaparin group (1.7 percent) and none in the heparin group (Table 29).

##### Enoxaparin Versus Extended-Duration Enoxaparin

Bleeding events requiring reoperation occurred in one patient in the short-term prophylaxis group (0.75 percent) and one patient in the extended prophylaxis group (0.56 percent).131 There was no significant difference between the two groups in the mean drop in hemoglobin during surgery (Table 29).

##### Enoxaparin at Standard Versus Augmented Dosing

In the study by Scholten et al.,145 among 92 patients receiving enoxaparin 30 mg twice daily (standard dosing), there was one bleeding event that required transfusion (1.1 percent). Among the 389 patients who received 40 mg twice daily (augmented), there was a single bleeding event requiring re-operation. Singh et al. reported no bleeding events reported among the 11 patients receiving standard dose enoxaparin (30 mg twice daily), while among the 159 patients who received augmented dosing, there were five bleeding episodes requiring transfusion (3.1 percent), one of which required reoperation (0.6 percent).146 Hamad et al. reported three bleeding events requiring transfusion among the 264 patients receiving standard dosing (1.1 percent), and three bleeding events requiring transfusion in 180 patients receiving augmented dosing (1.7 percent)143 (Table 29).

##### Enoxaparin at Standard Versus Reduced Dosing

Bleeding requiring transfusion was reported in one patient receiving reduced dosing enoxaparin (0.4 percent) and in three patients receiving standard dosing (1.1 percent)143 (Table 29).

##### Differing Augmented Enoxaparin Dosing Regimens, 40 mg Twice Daily Versus 50 or 60 mg Twice Daily

Borkgren-Okonek et al. reported major bleeding events in five (4.03 percent) of the 124 patients receiving 40 mg twice daily, one of whom required reoperation (0.8 percent). One patient who received 60 mg twice daily developed major bleeding (1.0 percent), but did not require reoperation.129 Singh et al. reported four bleeding events (2.8 percent) among the 145 patients receiving 40 mg twice daily, one of which one required reoperation (0.7 percent). There was one major bleeding event (20.0 percent) among the five patients receiving 60 mg twice daily; the patient did not require reoperation.146 Ojo et al.reported no bleeding events in either group.144 Simone et al. reported one bleeding episode (4.2 percent), which required transfusion among the 24 patients receiving 40 mg twice daily, and no bleeding events among the 16 patients receiving 60 mg twice daily147 (Table 29).

#### Anti-Xa levels

Two studies reported on this outcome.132,133

##### Enoxaparin at Standard Versus Augmented Dosing

One of the studies that included patients receiving either standard dose enoxaparin (30 mg twice daily) or augmented dosing (40 mg twice daily), and studied only pharmacokinetic endpoints, specifically anti-Xa levels drawn after the first and third doses of the drug, measured 4 hours after the dose.132 The study defined appropriate prophylactic levels as 0.18-0.44 units/mL. Nineteen patients (mean weight 141.6 kg) received the 30 mg twice-daily dose, and 33 patients (mean weight 135.6 kg) received the 40 mg twice-daily dose. Patients receiving 30 mg twice daily had mean anti-Xa levels of 0.06 units/mL after the first dose, and 0.8 units/mL after the third dose. Levels were 0.14 and 0.15 units/mL, respectively, in patients receiving 40 mg doses. None of the patients receiving 30 mg doses had therapeutic levels after the first dose, and only 9 percent had therapeutic levels after the third dose. In those receiving 40 mg, 31 and 42 percent were therapeutic after the first and third doses, respectively.

##### Differing Augmented Enoxaparin Dosing Regimens, 40 mg Twice Daily Versus 50 or 60 mg Twice Daily

In the study by Simone et al., 24 patients (mean weight 135 kg) received 40 mg twice daily and 16 patients (mean weight 127 kg) received 60 mg twice daily.147 The study measured anti-Xa levels 4 hours after the first and third doses of drug and defined appropriate prophylactic levels as 0.18-0.44 units/mL. Mean anti-Xa levels were 0.173 units/mL in the 40 mg group and 0.261 units/mL in the 60-mg group, after the first dose. After the third dose, levels were 0.21 and 0.43 units/mL respectively. None of the patients receiving the 60 mg dose remained subtherapeutic after three doses, in contrast to 44 percent of those receiving 40 mg. However, there were no supratherapeutic levels in the patients receiving 40 mg, in contrast to 57 percent of the levels in patients receiving 60 mg doses.

### Risk of Bias

All of the observational studies, except one which was rated as moderate risk of bias 149were rated to have a high risk of bias due to severe methodological limitations in design and analysis. The preference of the surgical team or the protocol employed at the center during a particular timeframe usually defined the prophylactic strategy. Some authors described allocating interventions based on real or perceived risk factors for postoperative VTE, such as prior history of VTE, age, degree of immobility, or severity of obesity; or varied the dose of pharmacotherapy based on patient weight in an effort to ensure that patients received an adequate prophylactic blood level of the drug. This targeted prophylactic approach would tend to bias these studies toward poorer efficacy of more aggressive prophylactic strategies employed in riskier patients. In keeping with the low numbers of patients and events, none of the studies performed multivariable adjustments to account for patient differences according to intervention allocation, except one that sought to define the efficacy of IVC filters by comparing those who got filters with those who did not by propensity score methods.149 None of the studies focusing on differing intensity, timing, or duration of pharmacologic prophylaxis used multivariate adjustment to account for differences between patients who received different prophylactic strategies.

### Strength of Evidence

Among studies that evaluated IVC filters, we rated the overall risk of bias as high for all outcomes. We considered the evidence direct for all outcomes other than anti-Xa levels. The random effects meta-analysis forest plot for IVC filter vs no filter on the outcomes of PE, mortality and DVT are shown in Figures 11–13. We rated the strength of evidence as low to support that prophylactic filters do not decrease the risk of PE relative to no use. We based this rating on consistent and direct evidence from high risk of bias studies (Table 30). There was low statistical heterogeneity in the risk of PE associated with IVC filters (I^2^ = 16.3%); all studies had confidence intervals that overlapped unity. We rated the strength of evidence as insufficient to support that prophylactic filters increase the risk of postoperative DVT. We based this rating on consistent and direct evidence from high risk of bias studies with a confidence interval spanning unity (Table 30). The estimate of an increased risk of DVT with IVC filters was precise in the registry study by Li,136 with point estimates suggesting increased risk of DVT with IVC filters in all studies. Statistical heterogeneity was high (I^2^ = 62.6%). We rated the strength of evidence as low to support that prophylactic filters are associated with an increased risk of mortality. We based this rating on consistent, precise and direct evidence from moderate and high risk of bias studies (Table 30). There was no statistical heterogeneity in the risk of mortality associated with IVC filters (I^2^ = 0.0%). Although one small study reported an effect that was opposite to the direction of effect in other studies, the width of the confidence interval overlapped with other studies showing an increased risk.

Figure 11 Relative risk forest plot (random effects) inferior vena cava filters versus no filters in bariatric surgery patients on PE

CI = confidence interval; IVCF = inferior vena cava filter; RR = relative risk

Figure 11 describes the relative risk of PE among bariatric surgery patients who received IVC filters vs no filters. Five studies are included in this figure

Figure 12 Relative risk forest plot (random effects) inferior vena cava filters versus no filters in bariatric surgery patients on DVT

CI = confidence interval; IVCF = inferior vena cava filter; RR = relative risk

Figure 12 describes the relative risk of DVT among bariatric surgery patients who received IVC filters vs no filters. Four studies are included in this figure

Figure 13 Relative risk forest plot (random effects) inferior vena cava filters versus no filters in bariatric surgery patients on mortality

CI = confidence interval; IVCF = inferior vena cava filter; RR = relative risk

† Composite endpoint of mortality or permanent disability.

Figure 13 describes the relative risk of Mortality among bariatric surgery patients who received IVC filters vs no filters. Four studies are included in this figure

Table 30 Body of evidence for inferior vena cava filter versus controls for the prevention of pulmonary embolism in patients undergoing bariatric surgery

Author, Year | Outcomes | Risk of Bias | Directness | Precision # | Consistency | Magnitude of Effect
Filter vs. No Filter
| PE | High | Direct | Precise | Consistent | Low grade evidence to support that prophylactic IVCFs do not reduce PE in patients undergoing bariatric surgery compared with controls RR = 0.91 (95% CI = 0.32 to 2.57;p=0.858 ; 1^2^ =16.3%)
Gargiulo, N.J., 2006^135^ | | High | Direct | Precise | | 0% vs 2.6%
Li, W., 2012^136^ | | High | Direct | Precise | | 0.31% vs 0.12%; p=0.33
Obeid, F. N., 2007^138^ | | High | Direct | Imprecise | | 0.8 vs 0.6%; p=0.69
Overby, D. W., 2009^139^ | | High | Direct | Imprecise | | 0.6% vs 2.9%; p=0.22
| Fatal PE | High | Direct | Imprecise | Unknown | Insufficient evidence to comment on effectiveness of IVCF vs. controls in reducing fatal PE in patients undergoing bariatric surgery
Gargiulo, N.J., 2006^135^ | | High | Direct | Imprecise | | 0% vs 11.1%
| DVT | High | Direct | Imprecise | Consistent | Insufficient evidence to support that IVCFs increase DVT in patients undergoing bariatric surgery compared with controls RR = 2.77 ( 95% CI=0.87 to 8.85; p=0.086 ;1^2^ =62.6%)
Gargiulo, N.J., 2006^135^ | | High | Direct | Precise | | 3.4% vs NR
Li, W., 2012^136^ | | High | Direct | Precise | | 0.93% vs 0.12%; p<0.001
Obeid, F. N., 2007^138^ | | High | Direct | Imprecise | | 1.2% vs 0.65%; p=0.56
Overby, D. W., 2009^139^ | | High | Direct | Imprecise | | 3.1% vs 2.4% p=0.74
| VTE | Moderate | Direct | Precise | Unknown | Insufficient evidence to comment on effectiveness of IVCF vs controls in reducing VTE in patients undergoing bariatric surgery
Birkmeyer, N. J., 2010^149^ | | Moderate | Direct | Precise | Unknown | 2.0% vs 0.5%; p<0.0001
| Mortality ** | High | Direct | Precise | Consistent | Low grade evidence to support that IVCFs are associated with increased mortality in patients undergoing bariatric surgery RR =3.63 (95% CI=1.99 to 6.61;p=<0.05; 1^2^=0.0%)
Birkmeyer, N. J., 2010^149,†^ | | Moderate | Direct | Precise | | 1.9% vs 0.5% p<0.0001
Gargiulo, N.J., 2006^135^ | | High | Direct | Imprecise | | 0% vs. 1.4%
Li W., 2012^136^ | | High | Direct | Precise | | 0.31% vs. 0.03%; p=0.003
Obeid, F. N., 2007^138^ | | High | Direct | Imprecise | | 0.8% vs. 0.2%; P=0.37

CI = confidence interval; DVT = deep venous thrombosis; PE = pulmonary embolism; RR = relative risk ; VTE = venous thromboembolism

† There were no randomized controlled trials; Reported on mortality and permanent disability.

** Mortality rated as insufficient despite the absence of statistical heterogeneity ( I^2^=0%) because of clinical heterogeneity with filters being channeled to high risk patients.

# See Figure 12- 14 for ratings on precision.

Table 31 Body of evidence for pharmacological prophylaxis for the prevention of venous thromboembolism in patients undergoing bariatric surgery

Author, Year | Outcomes | Risk of Bias | Directness | Precision | Consistency | Magnitude of Effect
Enoxaparin vs. Unfractionated Heparin
| PE | High | Direct | Imprecise | Unknown | Insufficient evidence to comment on effectiveness of enoxaparin vs. unfractionated heparin in reducing PE in patients undergoing bariatric surgery
Kothari, S. 2007^130^ | | High | Direct | Imprecise | | 0% vs 0.4%; p=0.99
| DVT | High | Direct | Unknown | Unknown | Insufficient evidence to comment on effectiveness of enoxaparin vs. unfractionated heparin in reducing DVT in patients undergoing bariatric surgery
Kothari, S. 2007^130^ | | High | Direct | Unknown | | 0% vs 0%
| Major bleeding # | High | Direct | Precise | Unknown | Insufficient evidence to comment on effectiveness of enoxaparin vs. unfractionated heparin in reducing major bleeding in patients undergoing bariatric surgery
Kothari, S. 2007^130^ | | High | Direct | Precise | | 5.9% vs 1.3%; p=0.011
| Mortality | High | Direct | Unknown | Unknown | Insufficient evidence to comment on effectiveness of enoxaparin vs. unfractionated heparin in reducing mortality in patients undergoing bariatric surgery
Kothari, S. 2007^130^ | | High | Direct | Unknown | | 0% vs 0%
Enoxaparin vs. Extended Duration of Enoxaparin
| PE | High | Direct | Unknown | Unknown | Insufficient evidence to comment on effectiveness of enoxaparin vs. extended-duration enoxaparin in reducing PE in patients undergoing bariatric surgery
Raftopoulos, I., 2008^131^ | | High | Direct | Unknown | | 2.3% vs 0%
| VTE | High | Direct | Precise | Unknown | Insufficient evidence to comment on effectiveness of enoxaparin vs. extended-duration enoxaparin in reducing VTE in patients undergoing bariatric surgery
Raftopoulos, I., 2008^131^ | | High | Direct | Precise | | 4.6% vs 0% ;P=0.006
| DVT | High | Direct | Unknown | Unknown | Insufficient evidence to comment on effectiveness of enoxaparin vs. extended-duration enoxaparin in reducing DVT in patients undergoing bariatric surgery
Raftopoulos, I., 2008^131^ | | High | Direct | Unknown | | 2.3% vs 0%
| Major bleeding # | High | Direct | Imprecise | Unknown | Insufficient evidence to comment on effectiveness of enoxaparin vs. extended-duration enoxaparin in reducing major bleeding in patients undergoing bariatric surgery
Raftopoulos, I., 2008^131^ | | High | Direct | Imprecise | | 4.5% vs 0% ;p= 0.06
| Mortality | High | Direct | Imprecise | Unknown | Insufficient evidence to comment on effectiveness of enoxaparin vs. extended-duration enoxaparin in reducing mortality in patients undergoing bariatric surgery
Raftopoulos, I., 2008^131^ | | High | Direct | Imprecise | | 0% vs 0%; p = NS
Enoxaparin at Standard Dosing vs. Augmented Dosing
| PE | High | Direct | Unknown | Inconsistent | Insufficient evidence to comment on effectiveness of enoxaparin at standard dosing vs. augmented dosing in reducing PE in patients undergoing bariatric surgery
Hamad, G.G., 2005^143^ | | High | Direct | Unknown | | 0.4% vs 0.6%
Scholten, D. J., 2002^145^ | | High | Direct | Unknown | | 4.4% vs 0%
Singh, K., 2011^146^ | | High | Direct | Unknown | | 0% vs 0%
| DVT | High | Direct | Unknown | Inconsistent | Insufficient evidence to comment on effectiveness of enoxaparin at standard dosing vs. augmented dosing in reducing DVT in patients undergoing bariatric surgery
Hamad, G.G., 2005^143^ | | High | Direct | Unknown | | 0% vs 0%
Scholten, D. J., 2002^145^ | | High | Direct | Unknown | | 1.1% vs 0.6%
Singh, K., 2011^146^ | | High | Direct | Unknown | | 0% vs 0%
| VTE | High | Direct | Precise | Unknown | Insufficient evidence to comment on effectiveness of enoxaparin at standard dosing vs. augmented dosing in reducing VTE in patients undergoing bariatric surgery
Scholten, D. J., 2002^145^ | | High | Direct | Precise | | 5.4% vs 0.6% ; p <0.01
| Bleeding | High | Direct | Unknown | Consistent | Insufficient evidence to comment on effectiveness of enoxaparin at standard dosing vs. augmented dosing in reducing bleeding in patients undergoing bariatric surgery
Hamad, G.G., 2005^143^ | | High | Direct | Unknown | | 0% vs 1.7%
Singh, K., 2011^146^ | | High | Direct | Unknown | | 0% vs 2.8%
Scholten, D. J., 2002^145^ | | High | Direct | Imprecise | | 1.1% vs 0.26%; p=NS

DVT = deep venous thrombosis; NR = not reported; NS = not significant; PE = pulmonary embolism; VTE = venous thromboembolism

# Requiring transfusion.

We rated the strength of evidence as insufficient for all outcomes and comparisons for the pharmacologic interventions. We based this rating on the overall risk of bias as high for all comparisons and outcomes (Table 31). We considered most of the evidence direct except for the surrogate outcome of anti-Xa levels. We rated the strength of evidence as insufficient for all outcomes and comparisons because of the inconsistencies and imprecision in the body of evidence from such high risk of bias studies.

### Applicability

Patient characteristics were consistent with those expected in the bariatric surgery population, including obese middle-aged patients of both sexes. Types of surgeries included the main types of bariatric procedures currently employed in the United States. (including Roux-en-Y gastric bypass and adjustable gastric banding); most surgeries were laparoscopic, consistent with current practice. Most studies did not report race, so we cannot make firm conclusions related to potential interactions between race and prophylactic strategy. Although many studies reported single center experiences, patient characteristics and surgery types appear relatively consistent across study centers. The single-center nature of these studies, by itself, is not a major factor limiting generalizability since the characteristics of patients recruited were similar to those in other centers. However, several of these studies targeted specific pharmacologic strategies and IVC filters for patients with more severe obesity such as BMI> 55 kg/m^2^. Thus the applicability of these findings to those with lower levels of BMI is uncertain.

## Key Question 7 What are the comparative effectiveness and safety of pharmacologic prophylaxis for prevention of venous thromboembolism during hospitalization of obese and underweight patients?

### Key Points and Evidence Grades

- The strength of evidence is insufficient to comment on the effectiveness of prophylaxis with fixed dose dalteparin over placebo in reducing VTE in hospitalized obese patients
- The strength of evidence is insufficient to comment on the effectiveness of prophylaxis with fixed dose dalteparin over placebo in reducing major bleeding and mortality in hospitalized obese patients
- The strength of evidence is insufficient to comment on whether fixed dose enoxaparin at 40 mg dose compared with various weight based dosing regimens (0.4 mg/kg or 0.5 mg/kg of enoxaparin) differ in achieving target anti-factor Xa level in obese hospitalized patients
- There were no studies that specifically evaluated underweight patients.

### Study Characteristics

Two studies reported on this Key Question. A single retrospective subgroup analysis of obese patients (BMI>30 in men, and BMI>28.6 in women) from the Prospective Evaluation of Dalteparin Efficacy for Prevention of VTE in Immobilized Patients Trial (PREVENT) reported on the comparative effectiveness and safety of medications for the prevention of VTE in obese patients.150 The PREVENT trial was a multicenter RCT conducted in multiple hospitals in North America and Europe that enrolled 3,706 medically ill patients and randomized them to receive either a daily dose of 5,000 U of dalteparin or placebo. The inclusion criteria were acute congestive heart failure (New York Heart Association III and IV), acute respiratory failure, infectious disease, acute rheumatic disease, or inflammatory bowel disease. In patients with infectious, rheumatic, or inflammatory bowel diseases, at least one additional VTE risk factor had to be present: chronic congestive heart failure, age of 75 years or above, obesity, varicose veins, chronic oxygen requirement, cancer, history of VTE, hormone therapy, or a myeloproliferative syndrome. The exclusion criteria included coagulopathies, advanced liver and kidney disease, as well as recent major surgery.

Freeman and colleagues sequentially assigned 31 medically ill patients with extreme obesity (defined by BMI>=40kg/m^2^) to a fixed dose of enoxaparin at 40 mg daily (control group, n=11); weight based lower dose enoxaparin 0.4mg/kg (n=9); and weight based higher dose enoxaparin 0.5mg/kg (n=11). The inclusion criteria was >18 years of age, BMI>40kg/m^2^ and having at least one additional major VTE risk factor (age>70 years, heart failure, respiratory failure, previous VTE, cancer, stroke, sepsis and immobility). Patients on anticoagulation, or other risk of bleeding, estimated creatinine clearance<30mL/min, or surgery or trauma within 14 days were excluded (Table 32).

Table 32 Study, participant, and intervention characteristics for KQ 7

Author, Year | Study Design | Arm, n | Drug Name, Dose | Age (Years) Mean±SD | Male, n (%) | BMI Mean±SD | Weight Mean±SD | Prior History of VTE, n (%)
Freeman A, 2012^151^ | Prospective cohort study | Fixed-dose Enoxaparin, 11 | Enoxaparin, 40 mg daily | 45.5 ± 7.2 | 2 (18.2) | 63.4 ± 11.6 | 175.0 ± 39.9 | NR
Freeman A, 2012^151^ | Prospective cohort study | Lower-dose Enoxaparin, 9 | Enoxaparin, 0.4 mg/kg daily | 43.8 ± 15.7 | 6 (66.7) | 60.7 ± 12.4 | 171.2 ± 42.8 | NR
Freeman A, 2012^151^ | Prospective cohort study | Higher-dose Enoxaparin, 11 | Enoxaparin 0.5 mg/kg daily | 42.7 ± 12.3 | 3 (27.3) | 61.3 ± 12.2 | 179.6 ± 30.3 | NR
Kucher, N., 2005^150^ | Randomized Controlled Trial | Dalteparin, 558 | Dalteparin | NR | NR | NR | NR | NR
Kucher, N., 2005^150^ | Randomized Controlled Trial | Placebo, 560 | Placebo | NR | NR | NR | NR | NR

BMI = body mass index; NR = not reported; VTE = venous thromboembolism

* Median reported.

### Participant Characteristics

In the PREVENT trial, of the 1,118 obese patients, 396 were men and 722 were women; 91 percent were Caucasians, and the median BMI was 32.9 kg/m^2^. The top three primary medical diagnoses were New York Heart Association class III or IV heart failure, acute respiratory failure, and acute infectious diseases. In the Freeman study the average BMI was 62.1kg/m^2^ and did not differ between the 3 groups. The average age was 45.5, 43.8, and 42.7 years for fixed dose, lower dose, and higher dose respectively. The percentage of males in each group was 18.2 percent, 66.7 percent, and 27.3 percent, respectively, for fixed, lower and higher dose groups (Table 32).

### Intervention Characteristics

In the PREVENT trial, the study randomized patients to the dalteparin arm or placebo. The patients in dalteparin arm received 5,000 U subcutaneously daily or a placebo. Neither group received any additional concurrent prophylactic therapy. In the Freeman study patients were sequentially assigned to a fixed dose of enoxaparin at 40mg daily (control group, n=11); weight based lower dose enoxaparin 0.4mg/kg (n=9); and weight based higher dose enoxaparin 0.5mg/kg (n=11). All patients had anti-factor Xa level drawn upon study enrollment and then daily during their hospital stay (average 3 days) (Table 32).

### Outcomes

In the dalteparin vs placebo study the primary endpoint was a composite of symptomatic VTE, fatal PE, sudden death, and asymptomatic proximal DVT detected by compression ultrasound administered to all patients by day 21, the results of which were adjudicated by a core ultrasound laboratory blinded to group assignment. Secondary endpoints were proximal symptomatic and asymptomatic DVT, major and minor bleeding, and thrombocytopenia by day 21; as well as all-cause mortality by days 21 and 90.

In the Freeman study the primary outcome was the achievement of a peak anti-factor Xa level between 0.2-0.5IU/mL measured 4-6 hours after enoxaparin administration.

Total VTE among obese patients in the PREVENT trial, the composite primary end point, i.e., total VTE occurred in 2.8 percent of the dalteparin group (95% C.I. 1.3 to 4.3 percent), and in 4.3 percent of the placebo group (95% C.I. 2.5 to 6.2 percent), (RR, 0.64; 95% C.I. 0.32-1.28). Logistic regression analysis, modeling the probability of the primary endpoint, identified no statistical interaction between dalteparin efficacy and the presence or absence of obesity (P = 0.63). The efficacy of dalteparin in the prevention of total VTE was attenuated in obese patients with a BMI of 40 or greater. In addition to the above outcomes, the Kucher study also reported on the difference in outcomes between obese and non obese patients treated with dalteparin. There was no difference in rates of total VTE between non-obese and obese patients (2.8 vs 2.8%, p=0.5) but rates of mortality (14.3 vs 9.9%, p=0.0005) and major bleeding (1.6 vs 0%, p=0.005) were higher in non-obese patients treated with dalteparin compared with obese patients.

There were no symptomatic DVT or PE events with enoxaparin treatment in all three arms of Freeman study.

#### Fatal Pulmonary Embolisms

There were no fatal PEs in the obese patients in either study.

#### Mortality

In the PREVENT trial, among obese patients, dalteparin was associated with a statistically non-significant increase in mortality by day 21 (4.6 vs. 2.7 percent, P=0.14) and day 90 (9.9 vs. 8.6 percent P=0.36) compared with placebo.150

#### Major Bleeding

Dalteparin in obese patients was not associated with an increase in major hemorrhage by day 21 (0 vs. 0.7 percent placebo; P>0.99) compared with placebo in the PREVENT trial.150 No major bleeding was reported in the Freeman study.

#### Other Adverse Events

The PREVENT trial demonstrated that minor hemorrhage by day 21 and thrombocytopenia were not statistically significantly different between the patients with obesity randomized to dalteparin and to placebo. No adverse events are reported in the Freeman study.

#### Anti- Factor Xa levels

In the Freeman study, the anti-factor Xa level between 0.2 and 0.5IU/mL was achieved significantly more often (86% of the time) in the higher dose group than in the lower dose group (32%) and fixed dose group (19%) (P<0.001) and their peak anti-factor Xa level were also found to be significantly higher than the other two groups. Age, weight, BMI or creatinine clearance did not correlate with the peak anti-factor Xa level achieved and there were no adverse events reported. Additionally, 82% of patients in the fixed dose group had anti-Xa levels <0.2IU/mL while only 36% and 13% of patients in the lower dose and higher dose groups respectively had anti-factor Xa levels <0.2IU/mL (P<0.001). This finding suggests that weight based enoxaparin dosing at 0.5mg/kg achieves target anti-Xa levels more frequently in the extremely obese, medically ill patients compared with weight based lower dose enoxaparin 0.4mg/kg or fixed dose regimens of enoxaparin 40 mg. However these findings are imprecise, and need to be replicated in other studies.

### Risk of Bias

We rated the Kucher study to be at moderate risk of bias since this subgroup analysis among obese patients was not prespecified. It was unclear if the comparisons reported reflected the original randomized assignments. The Freeman study was also rated to be at moderate risk of bias due to limitations in study designs, lack of adequate randomization, blinding of subjects and adjustment for confounding.

### Strength of Evidence

We rated the strength of evidence as insufficient for all outcomes and comparisons. We based this rating on paucity of data available, moderate risk of bias studies with imprecision and unknown consistency in outcomes reported (Table 33).

Table 33 Body of evidence for pharmacological prophylaxis in obese patients

Author, Year | Outcomes | Patients (N) | Risk of Bias | Directness | Precision | Consistency | Magnitude of Effect | Strength of Evidence
Dalteparin vs. Placebo (In Obese Patients)
Kucher, N., 2005 150 | VTE | 1118 | Moderate | Direct | Imprecise | Unknown | 2.8% vs 4.3%; (RR, 0.64; 95% CI 0.32-1.28) | Insufficient evidence to comment on effectiveness of dalteparin vs placebo in reducing Total VTE in obese patients
Kucher, N., 2005 150 | Mortality | 1118 | Moderate | Direct | Imprecise | Unknown | 9.9% vs 8.6%, p=0.36 | Insufficient evidence to comment on effectiveness of Dalteparin vs placebo in reducing mortality in obese patients
Kucher, N., 2005 150 | Major bleeding | 1118 | Moderate | Direct | Imprecise | Unknown | 0% vs 0.7%, p>0.99 | Insufficient evidence to comment on safety of Dalteparin vs placebo in reducing major bleeding in obese patients
Enoxaparin 40 mg Daily vs. 0.4 mg/kg In Obese Patients
Freeman A, 2012 151 | Percentage of patients achieving target anti-Factor Xa level | 20 | Moderate | Indirect | Imprecise | Unknown | 19% vs 32%, p=NR | Insufficient evidence to comment on effectiveness of enoxaparin 40 mg daily versus 0.4 mg/kg in achieving peak anti- Factor Xa level in obese patients
Enoxaparin 40 mg Daily vs. 0.5 mg/kg In Obese Patients
Freeman A, 2012 151 | Percentage of patients achieving target anti-Factor Xa level | 22 | Moderate | Indirect | Precise | Unknown | 19% vs 86%,p<0.001 | Insufficient evidence to comment on effectiveness of enoxaparin 40 mg daily versus 0.5 mg/kg in achieving peak anti- Factor Xa level in obese patients
Enoxaparin 0.4 mg/kg vs. 0.5 mg/kg In Obese Patients
Freeman A, 2012 151 | Percentage of patients achieving target anti-Factor Xa level | 20 | Moderate | Indirect | Imprecise | Unknown | 32% vs 86%, p=NR | Insufficient evidence to comment on effectiveness of enoxaparin 0.4 mg/kg versus 0.5 mg/kg in achieving peak anti- Factor Xa level in obese patients

VTE = venous thromboembolism

### Applicability

The findings of this the subgroup analysis from the PREVENT trial might be generalized to obese elderly hospitalized patients. These findings should not be generalized to patients with coagulopathies, advanced liver and kidney disease as well as recent major surgery. The majority of participants (92%) were white limiting generalizability to other ethnic groups. Based on the finding from the Freeman study, weight based high dose enoxaparin may be expected to yield similar results in medically ill patients who are extremely obese, although the study is not adequately powered to determine clinical efficacy or safety in this patient population.

## Key Question 8 What are the comparative effectiveness and safety of pharmacologic prophylaxis for prevention of venous thromboembolism during hospitalization of patients with acute kidney injury, moderate renal impairment, or severe renal impairment not undergoing dialysis and patients receiving dialysis?

### Key Points and Evidence Grades

- The strength of evidence is insufficient to assess the comparative effectiveness and safety of pharmacologic prophylaxis for prevention of VTE during hospitalization of patients with acute kidney injury, moderate renal impairment, or severe renal impairment not undergoing dialysis and patients receiving dialysis. We found no studies that directly assessed our KQ.
- The strength of evidence is insufficient that UFH at 5,000 U three times daily increases the risk of major and minor bleeding events in patients with severely compromised renal function (i.e., glomerular filtration rate (GFR) <= 30 ml/min) compared with this dose in patients without severely compromised renal function.
- The strength of evidence as insufficient that enoxaparin significantly increases the risk of a major bleeding event compared with unfractionated heparin in patients with severe renal impairment (i.e., creatinine clearance < 30 mL/min).

### Study Characteristics

Five studies evaluated the effectiveness and safety of pharmacologic prophylaxis for prevention of VTE in patients with acute kidney injury, moderate renal impairment, or severe renal impairment not undergoing dialysis or patients receiving dialysis.30,51,152-154 Four studies used a randomized, controlled, parallel arm design30,51,155,156 and one was a cohort design assessing separate cohorts before and after a quality improvement intervention.157

### Participant Characteristics

The reported average age of the enrolled patients ranged from 61 to 88 years. The study populations were between 17 to 100 percent male. Data regarding the race/ethnicity of study participantswere not provided.

The studies used slightly different definitions of renal impairment. Two studies used a GFR or creatinine clearance of less than 30 ml/min to designate severe renal impairment and 30-60 ml/min to signify moderate renal impairment.51 157 Other definitions of renal impairment were a creatinine clearance (CrCl) between 20-50 ml/min,30 patients with a creatinine clearance between 30 and 50 mL/min156, and an estimated glomerular filtration rate less than 60 mL/min.155

### Intervention Characteristics

The studies included diverse regimens with virtually no overlap. Therefore, we summarize the pharmacologic regimens for each study below.

#### Randomized, Controlled Trials

Participants in the study by Bauersachs et al. received UFH at 5,000 IU three times daily. This trial also used certoparin, which is not approved in the U.S., therefore, we limited our summary to the UFH arm.51

In a study by Mahé et al., participants with a GFR of 20 to 50 ml/min received tinzaparin at 4,500 IU once daily or enoxaparin at 4,000 IU once daily.30

The trial by Dahl and colleagues randomly assigned patients who were over 75 years of age and/or had moderate renal dysfunction (defined as creatinine clearance between 30 and 49 mL/min) to receive enoxaparin 40 mg daily and dabigatran 150 mg daily.156

Shorr and colleagues published a post hoc subgroup analysis of a multicenter trial in which orthopedic patients were randomly assigned to receive desirudin 15 mg twice daily or enoxaparin 40 mg once daily.155

#### Prospective Cohort Studies

Elsaid, et al. assessed VTE and bleeding events associated with the use of unfractionated heparin 5,000 units either two or three times daily and enoxaparin 30 mg once or twice daily across patients stratified by renal function (creatinine clearance <30, 30-59, and ≥ 60 mL/min). They made assessments before and after an intervention that was designed to eliminate use of enoxaparin in patients whose creatinine clearance was less than 30 mL/min.157

### Outcomes

#### DVT/PE Outcomes

##### Randomized, Controlled Trial: Tinzaparin Versus Enoxaparin

The trial which had a main endpoint of anti-Xa of drug did not record any VTE events in patients who received tinzaparin or enoxaparin.30

##### Randomized, Controlled Trial: Certoparin Versus Unfractionated Heparin

As stated, one RCT compared the effectiveness of certoparin with unfractionated heparin.51 Since certoparin is not approved in the U.S., we could not use this trial to assess our KQ. However, the study stratified the results by renal function (GFR≤30 mL/min versus GFR>30 mL/min), allowing us to assess a question related to our KQ. The rate of DVT among patients treated with unfractionated heparin in patients with GFR greater than 30 mL/min was marginally lower than those with severe renal dysfunction (10.3 vs. 11.1 percent).

##### Randomized, Controlled Trial: Dabigatran Versus Enoxaparin

There was no significant difference detected in the rate of major venous thromboembolic event between patients receiving dabigatran (4.3%) and enoxaparin (9%, OR: 0.48, 95% CI: 0.13-1.73, p=0.271).156

##### Randomized, Controlled Trial: Desirudin Versus Enoxaparin

Patients receiving desirudin experienced a significantly lower rate of major VTE compared with patients receiving enoxaparin, 4.9% vs. 7.6%, p=0.019).155 This relationship was particularly pronounced for patients whose creatinine clearance was between 30-44 mL/min. In patients with this level of renal dysfunction, 11.1% of patients taking enoxaparinvs. 3.4% of those taking desirudinexperienced a major VTE (OR:3.52; 95% CI: 1.48-8.4; p=0.004).

##### Prospective Cohort Studies: Enoxaparin Versus Unfractionated Heparin

The prospective cohort study did not report the rates of VTE.

#### Serum Anti-Xa Levels

In one RCT, enoxaparin accumulated to a greater extent from day one to day eight in elderly patients with renal impairment than did tinzaparin.30 The ratio of maximum concentration on day eight to day one was 1.22 for enoxaparin and 1.05 for tinzaparin (p=0.016). The ratio of drug concentration area under the curve from day eight to day one yielded similar inferences, 1.26 for enoxaparin and 1.12 for tinzaparin.

#### Bleeding

In the RCT that assessed tinzaparin and enoxaparin, five bleeding events occurred in patients receiving tinzaparin versus four such events in patients receiving enoxaparin (p=0.67).30 Three of these were major bleeds, two in the tinzaparin group and one in the enoxaparin group (p=0.61).

The rate of major bleeding was significantly higher among patients randomly assigned to receive enoxaparin (4.7%) versus dabigatran (0%, p=0.039).156

There was no difference detected in the rate of major bleeding between patients who received desirudin (0.8%) versus enoxaparin (0.2%).155

Patients with severe renal dysfunction who received 5,000 IU of UFH three times a day had an increased risk for all bleeds (relative risk (RR): 3.4, 95% CI: 2.0-5.9), major bleeds (RR: 7.3, 95% CI: 3.3-16), and minor bleeds (RR: 2.6 (95% CI: 1.4-4.9) compared with patients treated with UFH without severe renal dysfunction.51

In the prospective cohort study, patients receiving enoxaparin were significantly more likely to experience a major bleeding episode compared with patients receiving unfractionated heparin (13.5% vs. 4.2%, RR: 3.2, 95% CI: 1.4-7.3). This result was largely driven by the subgroup of patients with a creatinine clearance less than 30 mL/min. For this subgroup with severe renal impairment, patients receiving enoxaparin were significantly more likely to have a bleed compared with patients receiving unfractionated heparin (18.9% vs. 4.1%, RR: 4.68, 95% CI: 1.1-20.6). There was no difference in the bleeding rates for patients whose creatinine clearances were greater than 60 mL/min.157

### Risk of Bias

We rated the prospective cohort study to have a high risk of bias because of limitations in the study design.157 We are unable to rule out differences between the groups confounding the relationship between the treatments of interest and outcomes. Additionally, we were unable to assess the level of surveillance for VTE or bleeding events. Of the four RCTs, three were assessed to be at moderate risk of bias and one at high risk of bias. The three moderate risk of bias RCTs were post hoc subgroup analyses of larger RCTs.51,155,156 We could not determine if these comparisons preserved the original randomization.51,155,156 The high risk of bias RCT carried out open randomization of study participants and failed to blind subjects and investigators30 (Appendix E).

### Strength of Evidence

We rated the strength of evidence as insufficient to assess the comparative effectiveness and safety of pharmacologic prophylaxis for prevention of VTE during hospitalization of patients with acute kidney injury, moderate renal impairment, or severe renal impairment not undergoing dialysis and patients receiving dialysis. We based this rating on the risk of bias associated with published studies and unknown consistency of evidence regarding associations that were reported.

We rated the strength of evidence as insufficient that 5,000 U of unfractionated heparin three times daily increases the risk of major and minor bleeding events in patients with severely compromised renal function (i.e., GFR <= 30 ml/min) compared with this dose in patients without severely compromised renal function. We based this rating on a high risk of bias of included studies and inconsistent evidence (Table 27).

Likewise, we rated the strength of evidence as insufficient that enoxaparin significantly increases the risk of a major bleeding event compared with unfractionated heparin in patients with severe renal impairment (i.e., creatinine clearance < 30 mL/min). We based this rating on a high risk of bias and inconsistent published evidence (Table 34).

Table 34 Body of evidence for pharmacological prophylaxis of venous thromboembolism in patients with renal insufficiency

Author, Year | Outcomes | Risk of Bias | Directness | Precision | Consistency | Strength of Evidence and Magnitude of Effect
Tinzaparin vs. Enoxaparin
| VTE | High | Direct | Imprecise | Unknown | Insufficient evidence to comment on effectiveness of tinzaparin vs. enoxaparin in reducing VTE in patients with renal insufficiency
Mahe, 2007^30^ | | High | Direct | Imprecise | Unknown | 0 events in 27 patients (tinzaparin) vs 0 events in 28 patients (enoxaparin)
| Bleeding | High | Direct | Imprecise | Unknown | Insufficient evidence to comment on the comparative safety of tinzaparin vs. enoxaparin on bleeding in patients with renal insufficiency
Mahe, 2007^30^ | | High | Direct | Imprecise | Unknown | 5 events/27 vs 4/28 ( p=0.67)
Dabigatran vs. Enoxaparin
| VTE | Moderate | Direct | Imprecise | Unknown | Insufficient evidence to comment on effectiveness of dabigatran in reducing VTE in severe renal compromise patients vs. enoxaparin
Dahl, 2012^156^ | | Moderate | Direct | Imprecise | Unknown | Insufficient evidence; 4.3% of patients receiving dabigatran experienced a VTE, compared with 6.4% of patients receiving enoxaparin (OR: 0.68, 95% CI: 0.31-1.48, p=0.334)
| Bleeding | Moderate | Direct | Precise | Unknown | Insufficient evidence to comment on the safety of dabigatran vs. Enoxaparin in terms of reducing major bleeding episodes in patients with renal compromise
Dahl, 2012^156^ | | Moderate | Direct | Precise | Unknown | Insufficient evidence; no events in patients receiving dabigatran (0/96) experienced a major bleed versus 4.7% (6/128) of patients receiving enoxaparin (p=0.039)
Desirudin vs. Enoxaparin
| VTE | Moderate | Direct | Precise | Unknown | Insufficient evidence to comment on effectiveness of desirudin in reducing VTE in severe renal compromise patients vs. enoxaparin
Storr, 2012^155^ | | Moderate | Direct | Precise | Unknown | Insufficient evidence; 4.9% of patients receiving desirudin experienced a VTE, compared with 7.6% of patients receiving enoxaparin (p=0.019)
| Bleeding | Moderate | Direct | Imprecise | Unknown | Insufficient evidence to comment on the safety of desirudin vs. Enoxaparin in terms of reducing major bleeding episodes in patients with renal compromise
Storr, 2012^155^ | | Moderate | Direct | Imprecise | Unknown | Insufficient evidence; 0.8% of patients receiving desirudin experienced a major bleed versus 0.2% of patients receiving enoxaparin (p=0.109)
Unfractionated Heparin vs. Enoxaparin
| Bleeding | High | Direct | Precise | Unknown | Insufficient evidence to comment on the safety of unfractionated heparin vs. Enoxaparin in terms of reducing major bleeding episodes in patients with renal compromise
Elsaid, 2012^157^ | | High | Direct | Precise | Unknown | Insufficient evidence to comment on the safety of unfractionated heparin vs. Enoxaparin in terms of reducing major bleeding episodes in patients with renal compromise. 4.1% vs. 13.5%, RR: 0.31, 95% CI: 0.14-0.71).
UHF in Severe Renal Compromise vs. All Other Renal Status
| VTE | Moderate | Direct | Imprecise | Unknown | Insufficient evidence to comment on effectiveness of UFH in reducing VTE in severe renal compromise patients vs. all other renal patients
Bauersachs, 2011^51^ | | Moderate | Direct | Imprecise | Unknown | Insufficient evidence; 2.6% of patients had a VTE event
| Bleeding | Moderate | Direct | Imprecise | Unknown | Insufficient evidence to comment on effectiveness of UFH in increasing bleeding in severe renal compromise patients vs. all other renal patients
Bauersachs, 2011^51^ | | Moderate | Direct | Imprecise | Unknown | Insufficient evidence; 13 events in 92 patients

UFH = unfractionated heparin; VTE = venous thromboembolism

### Applicability

The design, analytic goals, patient populations and studied regimens were very diverse among these studies. The results could generally be applied to patients with varying degrees of renal dysfunction.