# References

1 Heit J, Cohen A, Anderson FJ. Estimated annual number of incident and recurrent, non-fatal and fatal venous thromboembolism (VTE) events in the US. Blood. 2005;106:267A.
2 Raskob GE, Silverstein R, Bratzler DW, et al. Surveillance for Deep Vein Thrombosis and Pulmonary Embolism. Recommendations from a National Workshop. 2010;38(4 SUPPL):S502-S509.
3 Segal JB, Eng J, Jenckes MW, et al. Diagnosis and Treatment of Deep Venous Thrombosis and Pulmonary Embolism. Evidence Report/Technology Assessment Number 68. (Prepared by Johns Hopkins University Evidence-based Practice Center under Contract No. 290-97-0007.) AHRQ Publication No. 03-E016. Rockville, MD. Agency for Healthcare Research and Quality. March. 2003.
4 Geerts WH, Bergqvist D, Pineo GF, et al. Prevention of venous thromboembolism: American College of Chest Physicians Evidence-Based Clinical Practice Guidelines (8th Edition). Chest. 2008;133(6 Suppl):381S-453S. [pmid: 18574271].
5 Institute of Medicine. Initial national priorities for comparative effectiveness research. Washington, DC. National Academies Press. 2009.
6 Geerts WH, Code KI, Jay RM, Chen E, et al. A prospective study of venous thromboembolism after major trauma. 1994;331:1601-6.
7 Gillespie DL. Anticoagulation is the most appropriate method of prophylaxis against venous thromboembolic disease in high-risk trauma patients. Dis Mon. 2010;56(11):628-36. [pmid: 21081193].
8 Velmahos GC, Kern J, Chan L, et al. Prevention of Venous Thromboembolism After Injury. Evidence Report/ Technology Assessment No. 22 (Prepared by Southern California Evidence-based Practice Center/RAND under Contract No. 290-97-0001). Rockville, MD. Agency for Healthcare Research and Quality. 2000. AHRQ Publication No. 01-E004.
9 Bratton SL, Chestnut RM, Ghajar J, et al. Guidelines for the management of severe traumatic brain injury. V. Deep vein thrombosis prophylaxis. J Neurotrauma. Suppl 1. 2007;24:S32-6. [pmid: 17511543].
10 Jawa RS, Warren K, Young D, et al. Venous thromboembolic disease in trauma and surveillance ultrasonography. J Surg Res. May. 1. 2011;167(1):24-31. [pmid: 21176915].
11 Bush S, LeClaire A, Hampp C, et al. Review of a large clinical series: once-versus twice-daily enoxaparin for venous thromboembolism prophylaxis in high-risk trauma patients. J Intensive Care Med. 2011;26(2):111-5. [pmid: 21257630].
12 Pannucci CJ, Osborne NH, Wahl WL. Venous thromboembolism in thermally injured patients: analysis of the National Burn Repository. J Burn Care Res. 2011;32(1):6-12. [pmid: 21127423].
13 Ferguson RE, Critchfield A, Leclaire A, et al. Current practice of thromboprophylaxis in the burn population: a survey study of 84 US burn centers. Burns. 2005;31(8):964-6. [pmid: 16269216].
14 Faucher LD, Conlon KM. Practice guidelines for deep venous thrombosis prophylaxis in burns. J Burn Care Res. 2007;28(5):661-3. [pmid: 17667344].
15 Barba CA, Harrington C, Loewen M. Status of venous thromboembolism prophylaxis among bariatric surgeons: have we changed our practice during the past decade?. Surg Obes Relat Dis. 2009;5(3):352-6. [pmid: 19342305].
16 American Society for Metabolic and Bariatric Surgery Clinical Issues Committee. ASMBS position statement on prophylactic measures to reduce the risk of venous thromboembolism in bariatric surgery patients. Gainesville, FL. American Society for Metabolic and Bariatric Surgery. 2007. asmbs.org/2012/06/prophylactic-measures-to-reduce-the-risk-of-venous-thromboembolism-in-bariatric-surgery-patients/.
17 Society of American Gastrointestinal Endoscopic Surgeons (SAGES). Guidelines for deep venous thrombosis prophylaxis during laparoscopic surgery. Los Angeles. Society of American Gastrointestinal Endoscopic Surgeons. 2006. www.sages.org/publication/id/C/.
18 Muntz JE, Michota FA. Prevention and management of venous thromboembolism in the surgical patient: options by surgery type and individual patient risk factors. Am J Surg. 2010;199(1 Suppl):S11-20. [pmid: 20103080].
19 Institute for Clinical Systems Improvement (ICSI). Venous thromboembolism prophylaxis. 7th ed. Bloomington, MN. Institute for Clinical Systems Improvement. 2010. www.icsi.org/guidelines__more/catalog_guidelines_and_more/catalog_guidelines/catalog_cardiovascular_guidelines/vte_prophy/.
20 Winegar DA, Sherif B, Pate V, et al. Venous thromboembolism after bariatric surgery performed by Bariatric Surgery Center of Excellence Participants: analysis of the Bariatric Outcomes Longitudinal Database. Surg Obes Relat Dis. 2011;7(2):181-8. [pmid: 21421182].
21 Agarwal R, Hecht TE, Lazo MC, Umscheid CA. Venous thromboembolism prophylaxis for patients undergoing bariatric surgery: a systematic review. Surg Obes Relat Dis. 2010;6(2):213-20. [pmid: 20176509].
22 Folsom AR, Lutsey PL, Astor BC, et al. Atherosclerosis Risk in Communities Study. Chronic kidney disease and venous thromboembolism: a prospective study. Nephrol Dial Transplant. 2010;25(10):3296-301. [pmid: 20353958].
23 Nutescu EA, Spinler SA, Wittkowsky A, et al. Low-molecular-weight heparins in renal impairment and obesity: available evidence and clinical practice recommendations across medical and surgical settings. Ann Pharmacother. 2009;43(6):1064-83. [pmid: 19458109].
24 Daneschvar HL, Seddighzadeh A, Piazza G, et al. Deep vein thrombosis in patients with chronic kidney disease. Thromb Haemost. 2008;99(6):1035-9. [pmid: 18521505].
25 Cook DJ, Douketis J, Arnold D, et al. Bleeding and venous thromboembolism in the critically ill with emphasis on patients with renal insufficiency. Curr Opin Pulm Med. 2009;15(5):455-62. [pmid: 19617833].
26 Lovenox^®^ (enoxaparin sodium injection) for subcutaneous and intravenous use: prescribing information. Bridgewater, NJ. SanofiAventis. 2011. http://products.sanofi.us/lovenox/lovenox.html. August 8, 2011.
27 Innohep^®^ (tinzaparin sodium injection). Ballerup, Denmark. LEO Pharmaceutical Products. 2008. www.accessdata.fda.gov/drugsatfda_docs/label/2008/020484s011lbl.pdf. August 8, 2011.
28 Leizorovicz A. Tinzaparin compared to unfractionated heparin for initial treatment of deep vein thrombosis in very elderly patients with renal insufficiency: the IRIS Trial. Blood. 2008;112(11):166.
29 Fragmin^®^ (dalteparin sodium injection). New York, NY. Pfizer Inc. 2007. www.pfizer.com/files/products/uspi_fragmin.pdf. August 8, 2011.
30 Mahe I, Aghassarian M, Drouet L, et al. Tinzaparin and enoxaparin given at prophylactic dose for eight days in medical elderly patients with impaired renal function: a comparative pharmacokinetic study. Thromb Haemost. 2007;97(4):581-6. [pmid: 17393021].
31 Antevil JL, Sise MJ, Sack DI, et al. Retrievable vena cava filters for preventing pulmonary embolism in trauma patients: a cautionary tale. J Trauma. 2006;60:35-40. [pmid: 16456434].
32 Nicholson W, Nicholson WJ, Tolerico P, et al. Prevalence of fracture and fragment embolization of Bard retrievable vena cava filters and clinical implications including cardiac perforation and tamponade. Arch Intern Med. 2010;170(20):1827-31. [pmid: 20696949].
33 American College of Surgeons. National Trauma Data Bank^®^ (NTDB). www.facs.org/trauma/ntdb/index.html. December 23 2012.
34 Cherry RA, Nichols PA, Snavely TM, et al. Prophylactic inferior vena cava filters: do they make a difference in trauma patients?. J Trauma. 2008;65(3):544-8. [pmid: 18784566].
35 Rogers FB, Cipolle MD, Velmahos G, et al. Practice management guidelines for the prevention of venous thromboembolism in trauma patients: the EAST practice management guidelines work group. J Trauma. 2002;53(1):142-64. [pmid: 12131409].
36 Koehler DM, Shipman J, Davidson MA, et al. Is early venous thromboembolism prophylaxis safe in trauma patients with intracranial hemorrhage. J Trauma. 2011;70(2):324-9. [pmid: 21307729].
37 Abedi N, Papp A. A survey of current practice patterns in prophylaxis against venous thromboembolism (VTE) and gastrointestinal (GI) ulceration among Canadian burn centers. Burns. 2011.
38 Tufano A, Guida A, Di Minno MN, et al. Prevention of venous thromboembolism in medical patients with thrombocytopenia or with platelet dysfunction: a review of the literature. Semin Thromb Hemost. 2011;37(3):267-74. [pmid: 21455860].
39 Dahl OE, Quinlan DJ, Bergqvist D, et al. A critical appraisal of bleeding events reported in venous thromboembolism prevention trials of patients undergoing hip and knee arthroplasty. J Thromb Haemost. 2010;8(9):1966-75. [pmid: 20586919].
40 Rocha AT, de Vasconcellos AG, da Luz Neto ER, et al. Risk of venous thromboembolism and efficacy of thromboprophylaxis in hospitalized obese medical patients and in obese patients undergoing bariatric surgery. Obes Surg. 2006;16(12):1645-55. [pmid: 17217642].
41 Freeman AL, Pendleton RC, Rondina MT. Prevention of venous thromboembolism in obesity. Expert Rev Cardiovasc Ther. 2010;8(12):1711-21. [pmid: 21108553].
42 White RH, Zhou H, Romano PS. Incidence of idiopathic deep venous thrombosis and secondary thromboembolism among ethnic groups in California. Ann Intern Med. May. 1. 1998;128(9):737-40. [pmid: 9556467].
43 Schmid P, Fischer AG, Wuillemin WA. Swiss Medical Weekly: Low-molecular-weight heparin in patients with renal insufficiency. 2009;139:438-52.
44 Hirsh J, Bauer KA, Donati MB, et al. Parenteral anticoagulants: American College of Chest Physicians evidence-based clinical practice guidelines (8th edition). 2008;133:141S-59S.
45 Comparative effectiveness of pharmacologic and mechanical prophylaxis of venous thromboembolism among special populations, Research Protocol. http://www.effectivehealthcare.ahrq.gov/ehc/products/341/928/VTE-Special-Populations_Protocol_20120112.
46 Downs SH, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. J Epidemiol Community Health. 1998;52(6):377-84. [pmid: 9764259].
47 DerSimonian R, L N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-88. [pmid: 3802833].
48 Sweeting MJ, Sutton AJ, Lambert PC. What to add to nothing? Use and avoidance of continuity corrections in meta-analysis of sparse data. Stat Med. 2004;23(9):1351-75. [pmid: 15116347].
49 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. August. 2011. AHRQ Publication No. 10(11)-EHC063-EF. Chapters available at: www.effectivehealthcare.ahrq.gov.
50 Phelan HA, Wolf SE, Norwood SH, et al. A randomized, double-blinded, placebo-controlled pilot trial of anticoagulation in low-risk traumatic brain injury: The Delayed Versus Early Enoxaparin Prophylaxis I (DEEP I) study. J Trauma Acute Care Surg. 2012.
51 Bauersachs R, Schellong SM, Haas S, et al. CERTIFY: prophylaxis of venous thromboembolism in patients with severe renal insufficiency. Thromb Haemost. 2011;105(6):981-8. [pmid: 21505722].
52 Rajasekhar A, Lottenberg L, Lottenberg R, et al. A pilot study on the randomization of inferior vena cava filter placement for venous thromboembolism prophylaxis in high-risk trauma patients. J Trauma. 2011;71(2):323-9. [pmid: 21825934].
53 Rogers FB, Shackford SR, Ricci MA, et al. Prophylactic vena cava filter insertion in selected high-risk orthopaedic trauma patients. J Orthop Trauma. 1997;11(4):267-72. [pmid: 9258824].
54 Rogers FB, Shackford SR, Ricci MA, et al. Routine prophylactic vena cava filter insertion in severely injured trauma patients decreases the incidence of pulmonary embolism. J Am Coll Surg. 1995;180(6):641-7. [pmid: 7773475].
55 Wilson JT, Rogers FB, Wald SL, et al. Prophylactic vena cava filter insertion in patients with traumatic spinal cord injury: preliminary results. Neurosurgery. 1994;35(2):234-9. discussion 239. [pmid: 7969830].
56 Gosin JS, Graham AM, Ciocca RG, et al. Efficacy of prophylactic vena cava filters in high-risk trauma patients. Ann Vasc Surg. 1997;11(1):100-5. [pmid: 9061147].
57 Gorman PH, Qadri SF, Rao-Patel A. Prophylactic inferior vena cava (IVC) filter placement may increase the relative risk of deep venous thrombosis after acute spinal cord injury. J Trauma. 2009;66(3):707-12. [pmid: 19276742].
58 Khansarinia S, Dennis JW, Veldenz HC, et al. Prophylactic Greenfield filter placement in selected high-risk trauma patients. J Vasc Surg. 1995;22(3):231-5. discussion 235-6. [pmid: 7674465].
59 Rodriguez JL, Lopez JM, Proctor MC, et al. Early placement of prophylactic vena caval filters in injured patients at high risk for pulmonary embolism. J Trauma. 1996;40(5):797-802. discussion 802-4. [pmid: 8614083].
60 Rosenthal D, Kochupura PV, Wellons ED, et al. Gunther Tulip and Celect IVC filters in multiple-trauma patients. J Endovasc Ther. 2009;16(4):494-9. [pmid: 19702346].
61 Keller IS, Meier C, Pfiffner R, et al. Clinical comparison of two optional vena cava filters. J Vasc Interv Radiol. 2007;18(4):505-11. [pmid: 17446541].
62 O'Keeffe T, Thekkumel JJ, Friese S, et al. A policy of dedicated follow-up improves the rate of removal of retrievable inferior Vena Cava Filters in trauma patients. Am Surg. 2011;77(1):103-8. [pmid: 21396316].
63 Shang EK, Nathan DP, Carpenter JP, et al. Delayed complications of inferior vena cava filters: case report and literature review. Vasc Endovascular Surg. 2011;45(3):290-4. [pmid: 21278177].
64 Roberts A, Young WF. Prophylactic retrievable inferior vena cava filters in spinal cord injured patients. Surg Neurol Int. 2010;1:68. [pmid: 21125013].
65 Doody O, Given MF, Kavnoudias H, et al. Initial experience in 115 patients with the retrievable Cook Celect vena cava filter. J Med Imaging Radiat Oncol. 2009;53(1):64-8. [pmid: 19453530].
66 Phelan HA, Gonzalez RP, Scott WC, et al. Long-term follow-up of trauma patients with permanent prophylactic vena cava filters. J Trauma. 2009;67(3):485-9. [pmid: 19741388].
67 Hermsen JL, Ibele AR, Faucher LD, et al. Retrievable inferior vena cava filters in high-risk trauma and surgical patients: factors influencing successful removal. World J Surg. 2008;32(7):1444-9. [pmid: 18264826].
68 Lo CH, Leung M, Leong J. Inferior vena cava filters and lower limb flap reconstructions. ANZ J Surg. 2008;78(1-2):64-7. [pmid: 18199209].
69 Mahrer A, Zippel D, Garniek A, et al. Retrievable vena cava filters in major trauma patients: prevalence of thrombus within the filter. Cardiovasc Intervent Radiol. 2008;31(4):785-9. [pmid: 18247085].
70 Zakhary EM, Elmore JR, Galt SW, et al. Optional filters in trauma patients: can retrieval rates be improved?. Ann Vasc Surg. 2008;22(5):627-34. [pmid: 18619774].
71 Binkert CA, Sasadeusz K, Stavropoulos SW. Retrievability of the recovery vena cava filter after dwell times longer than 180 days. J Vasc Interv Radiol. 2006;17(2 Pt 1):299-302. [pmid: 16517775].
72 Gonzalez RP, Cohen M, Bosarge P, et al. Prophylactic inferior vena cava filter insertion for trauma: intensive care unit versus operating room. Am Surg. 2006;72(3):213-6. [pmid: 16553120].
73 Meier C, Keller IS, Pfiffner R, et al. Early experience with the retrievable OptEase vena cava filter in high-risk trauma patients. Eur J Vasc Endovasc Surg. 2006;32(5):589-95. [pmid: 16859935].
74 Meier C, Pfiffner R, Labler L, et al. Prophylactic insertion of optional vena cava filters in high-risk trauma patients. European Journal of Trauma. 2006;32(1):37-43.
75 Rosenthal D, Wellons ED, Lai KM, et al. Retrievable inferior vena cava filters: initial clinical results. Ann Vasc Surg. 2006;20(1):157-65. [pmid: 16378141].
76 Stefanidis D, Paton BL, Jacobs DG, et al. Extended interval for retrieval of vena cava filters is safe and may maximize protection against pulmonary embolism. Am J Surg. 2006;192(6):789-94. [pmid: 17161095].
77 Rosenthal D, Wellons ED, Lai KM, et al. Retrievable inferior vena cava filters: early clinical experience. J Cardiovasc Surg (Torino). 2005;46(2):163-9.
78 Hoff WS, Hoey BA, Wainwright GA, et al. Early experience with retrievable inferior vena cava filters in high-risk trauma patients. J Am Coll Surg. 2004;199(6):869-74. [pmid: 15555969].
79 Rosenthal D, Wellons ED, Levitt AB, Shuler FW, et al. Role of prophylactic temporary inferior vena cava filters placed at the ICU bedside under intravascular ultrasound guidance in patients with multiple trauma. J Vasc Surg. 2004;40(5):958-64. [pmid: 15557911].
80 Duperier T, Mosenthal A, Swan KG, et al. Acute complications associated with greenfield filter insertion in high-risk trauma patients. J Trauma. 2003;54(3):545-9. [pmid: 12634536].
81 Kurtoglu M, Guloglu R, Alimoglu O, et al. The late outcomes of vena cava filters in the prevention of pulmonary embolism. Ulus Travma Acil Cerrahi Derg. 2003;9(2):114-9. [pmid: 12836107].
82 Offner PJ, Hawkes A, Madayag R, et al. The role of temporary inferior vena cava filters in critically ill surgical patients. Arch Surg. 2003;138(6):591-4. discussion 594-5. [pmid: 12799328].
83 Carlin AM, Tyburski JG, Wilson RF, et al. Prophylactic and therapeutic inferior vena cava filters to prevent pulmonary emboli in trauma patients. Arch Surg. 2002;137(5):521-5. discussion 525-7. [pmid: 11982463].
84 Conners MS 3rd, Becker S, Guzman RJ, et al. Duplex scan-directed placement of inferior vena cava filters: a five-year institutional experience. J Vasc Surg. 2002;35(2):286-91. [pmid: 11854726].
85 Bochicchio GV, Scalea TM. Acute caval perforation by an inferior vena cava filter in a multitrauma patient: hemostatic control with a new surgical hemostat. J Trauma. 2001;51(5):991-2. discussion 993. [pmid: 11706350].
86 Rogers F, Lawler C. Dislodgement of an inferior vena cava filter during central line placement in an ICU patient: a case report. Injury. 2001;32(10):787-8. [pmid: 11754887].
87 Sekharan J, Dennis JW, Miranda FE, et al. Long-term follow-up of prophylactic greenfield filters in multisystem trauma patients. J Trauma. 2001;51(6):1087-90. discussion 1090-1. [pmid: 11740258].
88 Sing RF, Adrales G, Baek S, et al. Guidewire incidents with inferior vena cava filters. J Am Osteopath Assoc. 2001;101(4):231-3. [pmid: 11370548].
89 Sing RF, Jacobs DG, Heniford BT. Bedside insertion of inferior vena cava filters in the intensive care unit. J Am Coll Surg. 2001;192(5):570-5. discussion 575-6. [pmid: 11333093].
90 Greenfield LJ, Proctor MC, Michaels AJ, et al. Prophylactic vena caval filters in trauma: the rest of the story. J Vasc Surg. 2000;32(3):490-5. discussion 496-7. [pmid: 10957655].
91 Wojcik R, Cipolle MD, Fearen I, et al. Long-term follow-up of trauma patients with a vena caval filter. J Trauma. 2000;49(5):839-43. [pmid: 11086773].
92 Benjamin ME, Sandager GP, Cohn EJ Jr, et al. Duplex ultrasound insertion of inferior vena cava filters in multitrauma patients. Am J Surg. 1999;178(2):92-7. [pmid: 10487256].
93 Hughes GC, Smith TP, Eachempati SR, et al. The use of a temporary vena caval interruption device in high-risk trauma patients unable to receive standard venous thromboembolism prophylaxis. J Trauma. 1999;46(2):246-9. [pmid: 10029028].
94 Langan EM 3rd, Miller RS, Casey WJ 3rd, et al. Prophylactic inferior vena cava filters in trauma patients at high risk: follow-up examination and risk/benefit assessment. J Vasc Surg. 1999;30(3):484-88. [pmid: 10477641].
95 McMurtry AL, Owings JT, Anderson JT, et al. Increased use of prophylactic vena cava filters in trauma patients failed to decrease overall incidence of pulmonary embolism. J Am Coll Surg. 1999;189(3):314-20. [pmid: 10472933].
96 Tola JC, Holtzman R, Lottenberg L. Bedside placement of inferior vena cava filters in the intensive care unit. Am Surg. 1999;65(9):833-7. discussion 837-8. [pmid: 10484085].
97 Rogers FB, Strindberg G, Shackford SR, et al. Five-year follow-up of prophylactic vena cava filters in high-risk trauma patients. Arch Surg. 1998;133(4):406-11. discussion 412. [pmid: 9565121].
98 Sing RF, Smith CH, Miles WS, et al. Preliminary results of bedside inferior vena cava placement: safe and cost-effective. 1998;114:9-10.
99 Nunn CR, Neuzil D, Naslund T, et al. Cost-effective method for bedside insertion of vena caval filters in trauma patients. J Trauma. 1997;43(5):752-8. [pmid: 9390485].
100 Patton JH Jr, Fabian TC, Croce MA, Minard G, Pritchard FE, Kudsk KA. Prophylactic Greenfield filters: acute complications and long-term follow-up. J Trauma. 1996;41(2):231-6. discussion 236-7. [pmid: 8760529].
101 Zolfaghari D, Johnson B, Weireter LJ, et al. Expanded use of inferior vena cava filters in the trauma population. Surg Annu. 1995;27:99-105. [pmid: 7597558].
102 Leach TA, Pastena JA, Swan KG, et al. Surgical prophylaxis for pulmonary embolism. Am Surg. 1994;60(4):292-5. [pmid: 8129253].
103 Millward SF, Bormanis J, Burbridge BE, et al. Preliminary clinical experience with the Gunther temporary inferior vena cava filter. J Vasc Interv Radiol. 1994;5(6):863-8. [pmid: 7873866].
104 Rogers FB, Shackford SR, Wilson J, et al. Prophylactic vena cava filter insertion in severely injured trauma patients: indications and preliminary results. J Trauma. 1993;35(4):637-41. discussion 641-2. [pmid: 8411290].
105 Bach JR, Zaneuski R, Lee H. Cardiac arrhythmias from a malpositioned Greenfield filter in a traumatic quadriplegic. Am J Phys Med Rehabil. 1990;69(5):251-3. [pmid: 2222985].
106 Rosenthal D, Wellons ED, Hancock SM, et al. Retrievability of the Gunther Tulip vena cava filter after dwell times longer than 180 days in patients with multiple trauma. J Endovasc Ther. 2007;14(3):406-10. [pmid: 17723017].
107 Karmy-Jones R, Jurkovich GJ, Velmahos GC, et al. Practice patterns and outcomes of retrievable vena cava filters in trauma patients: an AAST multicenter study. J Trauma. 2007;62(1):17-24. discussion 24-5. [pmid: 17215729].
108 Smoot RL, Koch CA, Heller SF, et al. Inferior vena cava filters in trauma patients: efficacy, morbidity, and retrievability. J Trauma. 2010;68(4):899-903. [pmid: 20386285].
109 Wang Y, Pierce I, Gatehouse P, et al. Analysis of flow and wall shear stress in the peroneal veins under external compression based on real-time MR images. Med Eng Phys. 2011.
110 Sobus KM, Cawley MF, Alexander MA. Pulmonary embolism in the traumatic brain injured adolescent: report of two cases. Arch Phys Med Rehabil. 1994;75(3):362-4. [pmid: 8129594].
111 Yan SF, Mackman N, Kisiel W, et al. Hypoxia/Hypoxemia-Induced activation of the procoagulant pathways and the pathogenesis of ischemia-associated thrombosis. Arterioscler Thromb Vasc Biol. 1999;19(9):2029-35. [pmid: 10479642].
112 Mayle RE Jr, DiGiovanni CW, Lin SS, et al. Current concepts review: venous thromboembolic disease in foot and ankle surgery. Foot Ankle Int. 2007;28(11):1207-16. [pmid: 18021595].
113 Gramley F, Himmrich E, Mollnau H, Theis C, et al. Recent advances in the pharmacologicaltreatment of cardiacarrhythmias. Drugs Today. 2009;45(11):807-24. [pmid: 20126673].
114 Dudley RR, Aziz I, Bonnici A, et al. Early venous thromboembolic event prophylaxis in traumatic brain injury with low-molecular-weight heparin: risks and benefits. J Neurotrauma. 2010;27(12):2165-72. [pmid: 20939698].
115 Minshall CT, Eriksson EA, Leon SM, et al. Safety and efficacy of heparin or enoxaparin prophylaxis in blunt trauma patients with a head abbreviated injury severity score >2. J Trauma. 2011;71(2):396-400. [pmid: 21825943].
116 Kurtoglu M, Yanar H, Bilsel Y, et al. Venous thromboembolism prophylaxis after head and spinal trauma: intermittent pneumatic compression devices versus low molecular weight heparin. World J Surg. 2004;28(8):807-11. [pmid: 15457363].
117 Salottolo K, Offner P, Levy AS, et al. Interrupted pharmocologic thromboprophylaxis increases venous thromboembolism in traumatic brain injury. J Trauma. 2011;70(1):19-24. discussion 25-6. [pmid: 21217476].
118 Scudday T, Brasel K, Webb T, et al. Safety and efficacy of prophylactic anticoagulation in patients with traumatic brain injury. J Am Coll Surg. 2011;213(1):148-53. [pmid: 21459632].
119 Gersin K, Grindlinger GA, Lee V, et al. The efficacy of sequential compression devices in multiple trauma patients with severe head injury. J Trauma. 1994;37(2):205-8. [pmid: 8064917].
120 Saadeh Y, Gohil K, Bill C, et al. Chemical venous thromboembolic prophylaxis is safe and effective for patients with traumatic brain injury when started 24 hours after the absence of hemorrhage progression on head CT. Journal of Trauma and Acute Care Surgery. 2012;73(2):426-30. [pmid: 22846950].
121 Rubsamen K, Eschenfelder V. Reocclusion after thrombolysis: a problem solved by hirudin?. Blood Coagul. Fibrinolysis. 1991;2(1):97-100. [pmid: 1773004].
122 Reiff DA, Haricharan RN, Bullington NM, et al. Traumatic brain injury is associated with the development of deep vein thrombosis independent of pharmacological prophylaxis. J Trauma. 2009;66(5):1436-40. [pmid: 19430251].
123 Depew AJ, Hu CK, Nguyen AC, et al. Thromboembolic prophylaxis in blunt traumatic intracranial hemorrhage: a retrospective review. Am Surg. 2008;74(10):906-11. [pmid: 18942611].
124 Kim J, Gearhart MM, Zurick A, et al. Preliminary report on the safety of heparin for deep venous thrombosis prophylaxis after severe head injury. J Trauma. 2002;53(1):38-42. discussion 43. [pmid: 12131387].
125 Spurzem JR, Geraci SA. Outpatient management of patients following pulmonary embolism. Am J Med. 2010;123(11):987-90. [pmid: 20851365].
126 Still J, Friedman B, Furman S, et al. Experience with the insertion of vena caval filters in acutely burned patients. Am Surg. 2000;66(3):277-9. [pmid: 10759199].
127 Eriksson BI, Rosencher N, Friedman RJ, et al. Concomitant use of medication with antiplatelet effects in patients receiving either rivaroxaban or enoxaparin after total hip or knee arthroplasty. Thromb Res. 2012.
128 Friedman RJ, Kurth A, Clemens A, et al. Dabigatran etexilate and concomitant use of non-steroidal anti-inflammatory drugs or acetylsalicylic acid in patients undergoing total hip and total knee arthroplasty: no increased risk of bleeding. Thromb Haemost. 2012;108(1):183-90. [pmid: 22552763].
129 Borkgren-Okonek MJ, Hart RW, Pantano JE, et al. Enoxaparin thromboprophylaxis in gastric bypass patients: extended duration, dose stratification, and antifactor Xa activity. Surg Obes Relat Dis. 2008;4(5):625-31. [pmid: 18261965].
130 Kothari SN, Lambert PJ, Mathiason MA. A comparison of thromboembolic and bleeding events following laparoscopic gastric bypass in patients treated with prophylactic regimens of unfractionated heparin or enoxaparin. 2007;194:709-11.
131 Raftopoulos I, Martindale C, Cronin A, et al. The effect of extended post-discharge chemical thromboprophylaxis on venous thromboembolism rates after bariatric surgery: a prospective comparison trial. Surg Endosc. 2008;22(11):2384-91. [pmid: 18622558].
132 Rowan BO, Kuhl DA, Lee MD, et al. Anti-Xa levels in bariatric surgery patients receiving prophylactic enoxaparin. Obes Surg. 2008;18(2):162-6. [pmid: 18165884].
133 Simone EP, Madan AK, Tichansky DS, et al. Comparison of two low-molecular-weight heparin dosing regimens for patients undergoing laparoscopic bariatric surgery. Surg Endosc. 2008;22(11):2392-5. [pmid: 18594915].
134 Piano G, Ketteler ER, Prachand V, et al. Safety, feasibility, and outcome of retrievable vena cava filters in high-risk surgical patients. J Vasc Surg. 2007;45(4):784-8. discussion 788. [pmid: 17398387].
135 Gargiulo NJ 3rd, Veith FJ, Lipsitz EC, Suggs WD, Ohki T, Goodman E. Experience with inferior vena cava filter placement in patients undergoing open gastric bypass procedures. J Vasc Surg. 2006;44(6):1301-5. [pmid: 17055691].
136 Li W, Gorecki P, Semaan E, Briggs W, et al. Concurrent prophylactic placement of inferior vena cava filter in gastric bypass and adjustable banding operations in the Bariatric Outcomes Longitudinal Database. J Vasc Surg. 2012;55(6):1690-5. [pmid: 22360915].
137 Kardys CM, Stoner MC, Manwaring ML, et al. Safety and efficacy of intravascular ultrasound-guided inferior vena cava filter in super obese bariatric patients. Surg Obes Relat Dis. 2008;4(1):50-4. [pmid: 18065293].
138 Obeid FN, Bowling WM, Fike JS, et al. Efficacy of prophylactic inferior vena cava filter placement in bariatric surgery. Surg Obes Relat Dis. 2007;3(6):606-8. discussion 609-10. [pmid: 17936083].
139 Overby DW, Kohn GP, Cahan MA, et al. Risk-group targeted inferior vena cava filter placement in gastric bypass patients. Obes Surg. 2009;19(4):451-5. [pmid: 19127387].
140 Schuster R, Hagedorn JC, Curet MJ, et al. Retrievable inferior vena cava filters may be safely applied in gastric bypass surgery. Surg Endosc. 2007;21(12):2277-9. [pmid: 17440780].
141 Vaziri K, Devin Watson J, Harper AP, et al. Prophylactic Inferior Vena Cava Filters in High-Risk Bariatric Surgery. Obes Surg. 2010.
142 Van Ha TG, Dillon P, Funaki B, et al. Use of retrievable filters in alternative common iliac vein location in high-risk surgical patients. J Vasc Interv Radiol. 2011;22(3):325-9. [pmid: 21277796].
143 Hamad GG, Choban PS. Enoxaparin for thromboprophylaxis in morbidly obese patients undergoing bariatric surgery: findings of the prophylaxis against VTE outcomes in bariatric surgery patients receiving enoxaparin (PROBE) study. Obes Surg. 2005;15(10):1368-74. [pmid: 16354513].
144 Ojo P, Asiyanbola B, Valin E, et al. Post discharge prophylactic anticoagulation in gastric bypass patient-how safe?. Obes Surg. 2008;18(7):791-6. [pmid: 18386108].
145 Scholten DJ, Hoedema RM, Scholten SE. A comparison of two different prophylactic dose regimens of low molecular weight heparin in bariatric surgery. Obes Surg. 2002;12(1):19-24. [pmid: 11868291].
146 Singh K, Podolsky ER, Um S, et al. Evaluating the Safety and Efficacy of BMI-Based Preoperative Administration of Low-Molecular-Weight Heparin in Morbidly Obese Patients Undergoing Roux-en-Y Gastric Bypass Surgery. Obes Surg. 2011.
147 Schweitzer M, Steele KE, Lidor A, et al. Acute vena cava thrombosis after placement of retrievable inferior vena cava filter before laparoscopic gastric bypass. Surg Obes Relat Dis. 2006;2(6):661-3. [pmid: 16979958].
148 Veerapong J, Wahlgren CM, Jolly N, et al. Successful percutaneous retrieval of an inferior vena cava filter migrating to the right ventricle in a bariatric patient. Cardiovasc Intervent Radiol. Suppl 2. 2008;31:S177-81. [pmid: 18204951].
149 Birkmeyer NJ, Share D, Baser O, et al. Preoperative placement of inferior vena cava filters and outcomes after gastric bypass surgery. Ann Surg. 2010;252(2):313-8. [pmid: 20622663].
150 Kucher N, Leizorovicz A, Vaitkus PT, et al. Efficacy and safety of fixed low-dose dalteparin in preventing venous thromboembolism among obese or elderly hospitalized patients: a subgroup analysis of the PREVENT trial. Arch Intern Med. 2005;165(3):341-5. [pmid: 15710801].
151 Freeman A, Horner T, Pendleton RC, et al. Prospective comparison of three enoxaparin dosing regimens to achieve target anti-factor Xa levels in hospitalized, medically ill patients with extreme obesity. 2012;87(7):740-3.
152 Schmid P, Brodmann D, Fischer AG, et al. Study of bioaccumulation of dalteparin at a prophylactic dose in patients with various degrees of impaired renal function. J Thromb Haemost. 2009;7(4):552-8. [pmid: 19175499].
153 Schmid P, Brodmann D, Fischer AG, et al. Prospective observational cohort study of bioaccumulation of dalteparin at a prophylactic dose in patients with peritoneal dialysis. J Thromb Haemost. 2010;8(4):850-2. [pmid: 20088934].
154 Tincani E, Mannucci C, Casolari B, et al. Safety of dalteparin for the prophylaxis of venous thromboembolism in elderly medical patients with renal insufficiency: a pilot study. Haematologica. 2006;91(7):976-9. [pmid: 16757417].
155 Shorr AF, Eriksson BI, Jaffer A, et al. Impact of Stage 3B chronic kidney disease on thrombosis and bleeding outcomes after orthopedic surgery in patients treated with desirudin or enoxaparin: Insights from a randomized trial. J Thromb Haemost. 2012.
156 Dahl OE, Kurth AA, Rosencher N, et al. Thromboprophylaxis with dabigatran etexilate in patients over seventy-five years of age with moderate renal impairment undergoing or knee replacement. Int Orthop. 2012;36(4):741-8. [pmid: 22095136].
157 Elsaid KA, Collins CM. Initiative to improve thromboprophylactic enoxaparin exposure in hospitalized patients with renal impairment. Am J Health Syst Pharm. 2012;69(5):390-6. [pmid: 22345418].
158 Dossett LA, Adams RC, Cotton BA. Unwarranted national variation in the use of prophylactic inferior vena cava filters after trauma: an analysis of the National Trauma Databank. J Trauma. May. 2011;70(5):1066-70. discussion 1070-1. [pmid: 21610425].
159 Kidane B, Madani AM, Vogt K, et al. The use of prophylactic inferior vena cava filters in trauma patients: a systematic review. Injury. May. 2012;43(5):542-7. [pmid: 22386925].
160 Kaufman JA, Kinney TB, Streiff MB, et al. Guidelines for the use of retrievable and convertible vena cava filters: report from the Society of Interventional Radiology multidisciplinary consensus conference. J Vasc Interv Radiol. 2006;17(3):449-59. [pmid: 16567669].
161 Gould MK, Garcia DA, Wrem SM, et al. American College of Chest Physicians. Prevention of VTE in nonorthopedic surgical patients: Antithrombotic Therapy and Prevention of Thrombosis, 9th ed: American College of Chest Physicians Evidence-Based Clinical Practice Guidelines. Chest. Feb. 2012;141(2 Suppl):E227S-77S. [pmid: 22315263].
162 Wahl WL, Brandt MM, Ahrns KS, et al. Venous thrombosis incidence in burn patients: Preliminary results of a prospective study. 2002;23:97-102.
163 Guyatt GH, Akl EA, Crowther M, et al. Executive summary: Antithrombotic Therapy and Prevention of Thrombosis, 9th ed: American College of Chest Physicians Evidence-Based Clinical Practice Guidelines. Chest. Feb. 2012;141(2 Suppl):7S-47S. [pmid: 22315257].
164 Geerts WH, Bergqvist D, Pineo GF, et al. American College of Chest Physicians. Prevention of venous thromboembolism: American College of Chest Physicians Evidence-Based Clinical Practice Guidelines (8th Edition). Chest. Jun. 2008;133(6 Suppl):381S-453S. [pmid: 18574271].
165 Pincus KJ, Tata AL, Watson K. Risk of Venous Thromboembolism in Patients with Chronic Liver Disease and the Utility of Venous Thromboembolism Prophylaxis (June). Ann Pharmacother. 2012;46.
166 Koliscak L, Maynor L. Pharmacologic prophylaxis against venous thromboembolism in hospitalized patients with cirrhosis and associated coagulopathies. Am J Health Syst Pharm. Apr. 15. 2012;69(8):658-63. [pmid: 22472867].
167 Clements RH, Yellumahanthi K, Ballem N, et al. Pharmacologic prophylaxis against venous thromboembolic complications is not mandatory for all laparoscopic Roux-en-Y gastric bypass procedures. J Am Coll Surg. 2009;208(5):917-21. discussion 921-3. [pmid: 19476861].
168 Becattini C, Agnelli G, Manina G, et al. Venous thromboembolism after laparoscopic bariatric surgery for morbid obesity: clinical burden and prevention. Surg Obes Relat Dis. Jan-Feb. 2011;8(1):108-15. [pmid: 22014482].
169 Schulman S, Anger SU, Bergqvist D, et al. Definition of major bleeding in clinical investigations of antihemostatic medicinal products in surgical patients. 2010;8(1):202-4. [pmid: 19878532].
170 Gould MK, Garcia DA, Wren SM, et al. Prevention of VTE in nonorthopedic surgical patients: Antithrombotic Therapy and Prevention of Thrombosis, 9th ed: American College of Chest Physicians Evidence-Based Clinical Practice Guidelines. Chest. Feb. 2012;141(2 Suppl):e227S-77S. [pmid: 22315263].
171 Garcia DA, Baglin TP, Weitz JI, et al. American College of Chest Physicians. Parenteral anticoagulants: Antithrombotic Therapy and Prevention of Thrombosis, 9th ed: American College of Chest Physicians Evidence-Based Clinical Practice Guidelines. Chest. Feb. 2012;141(2 Suppl):E24S-43S. [pmid: 22315264].
172 Kahn SR, Lim W, Dunn AS, et al. American College of Chest Physicians. Prevention of VTE in nonsurgical patients: Antithrombotic Therapy and Prevention of Thrombosis, 9th ed: American College of Chest Physicians Evidence-Based Clinical Practice Guidelines. Chest. Feb. 2012;141(2 Suppl):E195S-226S. [pmid: 22315261].
173 Lin H, Faraklas I, Cochran A, Saffle J. Enoxaparin and antifactor Xa levels in acute burn patients. J Burn Care Res. 2011;32(1):1-5. [pmid: 21124231].
174 Lin H, Faraklas I, Saffle J, Cochran A. Enoxaparin dose adjustment is associated with low incidence of venous thromboembolic events in acute burn patients. J Trauma. Dec. 2011;71(6):1557-61. [pmid: 22027887].
175 Varadhan R, Stuart EA, Louis TA, et al. Review of Guidance Documents for Selected Methods in Patient Centered Outcomes Research: Standards in Addressing Heterogeneity of Treatment Effectiveness in Observational and Experimental Patient Centered Outcomes Research. 2012.