# Methods

The methods for this comparative effectiveness review (CER) follow the methods suggested in the Agency for Healthcare Research and Quality (AHRQ) “Methods Guide for Effectiveness and Comparative effectiveness Reviews” (www.effectivehealthcare.ahrq.gov/methodsguide.cfm) The main sections of this chapter reflect the elements of the protocol established for the CER; certain methods map to the PRISMA checklist. This systematic review was carried out according to a prespecified protocol registered at the AHRQ Web site.45

Our Evidence-based Practice Center (EPC) established a team and a work plan to develop this evidence report. The project involved recruiting key informants and technical experts, formulating and refining the questions, performing a comprehensive literature search, summarizing the state of the literature, constructing evidence tables, synthesizing the evidence, and submitting the report for peer review and public comment.

## Topic Refinement

The topic for this report was nominated via the EHC Web site. We recruited a panel of key informants to give input on key steps including the selection and refinement of the questions to be examined. The panel included local experts with expertise in bariatric surgery and external informants including expertise in burns, hematology, trauma, payer, and patient representatives.

With the input of the key informants, and staff of AHRQ and the Scientific Resources Center, we developed the Key Questions (KQs). Our draft KQs were posted on Effective Health Care Program Web site for public comment on August 16, 2011. We then refined the KQs based on the feedback received.

We recruited a Technical Expert Panel (TEP) which included experts in the prevention of venous thrombosis, on burn care, on trauma management, on bariatric surgery perioperative care, and hematologists. These technical experts provided high-level expertise to the Evidence-based Practice Center (EPC) during our development of the protocol for the comparative effectiveness review. Additionally, the Effective Health Care Program posted the KQs on its Web site for public comment and we discussed the KQs with the TEP. With input from the technical expert panel and representatives from AHRQ, we finalized the protocol. The protocol was posted on the Effective Health Care Program Web site on January 12th, 2012.^45^

## Search Strategy

We searched the following databases for primary studies through July 2012: MEDLINE^®^, Embase^®^, SCOPUS, CINAHL^®^, International Pharmaceutical Abstracts, and the Cochrane Library. We searched the clinicaltrials.gov in addition to these databases. We developed a search strategy for MEDLINE, accessed via PubMed^®^, based on medical subject headings (MeSH^®^) terms and text words of key articles that we identified a priori (Appendix B). We reviewed the reference lists of all included articles, relevant review articles, and related systematic reviews to identify articles which may have been missed in the original search. In addition, we requested and reviewed Scientific Information Packets (SIPs) provided by the pharmaceutical manufacturers. Our search did not have any language restrictions; we included non-English articles in our review but did not find any non-English article applicable to our project.

We conducted an updated literature search (of the same databases searched initially) concurrently with the peer review process. Any literature suggested by peer reviewers was investigated and, if appropriate, incorporated into the final review. We determined the appropriateness of all additional literature by the same methods described in this chapter.

## Study Selection

We reviewed titles followed by abstracts to identify randomized controlled trials (RCTs) or observational studies and case reports reporting on the effectiveness or safety of venous thromboembolism prevention in our selected populations (Table 2).

Table 2 Study inclusion and exclusion criteria

Category | Inclusion Criteria | Exclusion Criteria
Populations | - Human subjects (only); - Adults in special patient populations, including:; ○ Trauma; ○ Traumatic brain injury; ○ Burns; ○ Liver disease; ○ Antiplatelet therapy; ○ Bariatric surgery; ○ Obese and underweight; ○ Acute kidney injury, moderate renal impairment,; ○ severe renal impairment, renal replacement therapy | - Animal studies/models; - Children; - Pediatric; - Adolescent; - Adults in the following patient populations:; ○ Treatment of VTE; ○ Secondary prophylaxis; ○ Catheter thrombosis; ○ Antiphospholipid antibodies/other autoimmune diseases; ○ Cancer (malignancy, chemotherapy, radiotherapy); ○ Cardiovascular (coronary artery bypass graft surgery, percutaneous transluminal coronary angioplasty) patients on full-dose anticoagulation; ○ Pregnancy; ○ Disseminated intravascular coagulation; ○ Heparin-induced thrombocytopenia; ○ Congenital platelet disorders; ○ VTE prophylaxis for long distance travel; ○ Abdominal surgery; ○ Vascular surgery; ○ Urological surgery; ○ Gynecological surgery
Intervention | Studies that evaluate interventions or mechanical devices | Studies of agents that have not been approved for thromboprophylaxis in the United States or interventions not available in the United States will not be evaluated
Outcomes | - Symptomatic deep vein thrombosis; - Symptomatic pulmonary embolism; - Mortality; - Post-thrombotic syndrome; - Quality of life; - Length of hospital stay; - Length of ICU stay; - Bleeding (major, minor); - Heparin-induced thrombocytopenia; - Allergic reaction; - Mechanical device complications; - Infections; - Asymptomatic deep vein thrombosis; INR, PTT, factor Xa level (KQs 6, 7 and 8) | No data on relevant outcomes of interest
Type of Study | We included the following study designs; - Randomized controlled trials; - Prospective cohort studies; - Retrospective cohort studies; - Case-control studies; - Uncontrolled case-series for devices; - Case reports of device complications in the relevant special populations; - Case reports of pharmacologic therapies other than the known complications of bleeding and heparin-induced thrombocytopenia | - Case reports of efficacy; - Case reports of bleeding or heparin-induced thrombocytopenia associated with pharmacologic strategies; - In vitro studies; - Animal studies; - Cost-effectiveness studies; - Modeling studies; - Risk assessment studies; - Registries without descriptions of interventions; - Diagnostic studies; - Ecologic study designs; - Time-series designs; - No original data, commentary, or editorial; - Systematic reviews and meta-analysis

ICU = intensive care unit; INR = international normalized ratio; PTT = partial thromboplastin time; VTE = venous thromboembolism

Two investigators independently reviewed abstracts and we excluded the abstracts if both investigators agreed that the article met one or more of the exclusion criteria. We resolved disagreements by consensus. We recognized that much of the evidence about use of IVC filters would be from observational studies without comparison groups; therefore in our review of titles and abstracts we were inclusive of any design, including uncontrolled observational studies, case series and case reports, which described unanticipated harms from use of IVC filters.

For inclusion in this review, we required that studies enrolled or reported on patients who were members of our special populations. This included patients with traumatic brain injury, with burns requiring burn unit care, individuals with liver disease, patients receiving antiplatelet therapy, patients undergoing bariatric surgery, obese and underweight hospitalized medical patients, and patients with any degree of renal impairment. If the studies included a mixed population that included one of our special populations, the study either needed to report results separately for our population, or our population needed to comprise 80 percent or more of the total population. We excluded studies that were predominantly describing outcomes for children, adolescents, or pregnant women. We also excluded studies specifically evaluating any of our excluded patient populations: patients with antiphospholipid antibodies, cancer, disseminated intravascular coagulation, treatment of heparin-induced thrombocytopenia, or congenital platelet disorders. We excluded studies that used pharmacotherapy for treatment of venous thrombosis or that were evaluating secondary prevention of venous thrombosis outside of our stated patient populations. For our KQ 8 we excluded studies occurring among renal transplant recipients or those with nephrotic syndrome.

We included trials if the comparators were pharmacotherapies for prevention of venous thrombosis available in the United States, vena cava filters available in the United States, or mechanical devices or usual care practices. We did not require that observational studies about vena cava filters have comparison groups. We resolved differences regarding article inclusion through consensus adjudication, and a third reviewer audited a random sample to ensure consistency in the reviewing process.

At the point of full article review, we excluded studies that did not report on at least one of our outcomes of interest. These were: symptomatic or asymptomatic deep vein thrombosis or pulmonary embolism, fatal pulmonary embolism, mortality, post-thrombotic syndrome, quality of life, length of hospital stay or intensive care unit stay, bleeding, heparin-induced thrombocytopenia, allergic reactions, mechanical device complications, infections for all KQs. For KQ 7 and KQ 8 we also considered additional outcomes such as international normalized ratio, prothrombin time, or factor Xa levels (Table 3).

Table 3 PICOTS (population, intervention, comparator, outcome, timing, and setting) for each Key Question

PICOTS | KQ 1 | KQ 2 | KQ 3–KQ 5 | KQ 6 | KQ 7–KQ 8
Population(s) | - Trauma | - Traumatic brain injury | - Burns (KQ 3); - Liver disease (KQ 4); - Antiplatelet therapy (KQ 5) | - Bariatric surgery | - Obese and underweight patients (KQ 7); - Patients with acute kidney injury or moderate or severe renal impairment (KQ 8); - Patients receiving dialysis (KQ 8)
Interventions | - IVC filters | - Mechanical devices; - Pharmacologic (UFH LMWHs, factor Xa inhibitors, direct thrombin inhibitors); - IVC filters | - Mechanical devices; - Pharmacologic (UFH LMWHs, factor Xa inhibitors, direct thrombin inhibitors) | - Pharmacologic (UFH, LMWHs, factor Xa inhibitors, direct thrombin inhibitors); - Mechanical devices; - IVC filters | - Pharmacologic (UFH LMWHs, factor Xa inhibitors, direct thrombin inhibitors); - Mechanical devices
Comparators | - No IVC filters. (Studies that included usual care or those that did not use IVC filters as active controls including mechanical prophylaxis (e.g., SCDs, compression stockings) and pharmacologic controls | - Low-dose UFH, LMWHs, factor Xa inhibitors, direct thrombin inhibitors, and mechanical prophylaxis.; - Placebo- controlled studies, studies that used active controls, and uncontrolled studies. | - Low-dose UFH, LMWHs, factor Xa inhibitors, direct thrombin inhibitors, and mechanical prophylaxis.; - Placebo- controlled studies, studies that used active controls, and uncontrolled studies. | - Low-dose UFH, LMWHs, factor Xa inhibitors, direct thrombin inhibitors, and mechanical prophylaxis.; - Placebo- controlled studies, or studies that used active controls, and uncontrolled studies. | - Low-dose UFH, LMWHs, factor Xa inhibitors, direct thrombin inhibitors, and mechanical prophylaxis.; - Placebo- controlled studies, studies that used active controls, and uncontrolled studies.
Outcomes measures | - Symptomatic DVT; - Symptomatic PE; - Asymptomatic DVT; - Bleeding; - Mortality; - Post-thrombotic syndrome; - Quality of life; - Length of stay; - Allergic reaction; - Mechanical device complications; - Infections | - Symptomatic DVT; - Symptomatic PE; - Asymptomatic DVT; - Bleeding; - Mortality; - Post-thrombotic syndrome; - Quality of life; - Length of stay; - Length of ICU stay; - Heparin-induced thrombocytopenia; - Allergic reaction; - Mechanical device complications; - Infections | - Symptomatic DVT; - Symptomatic PE; - Asymptomatic DVT; - Bleeding; - Mortality; - Post-thrombotic syndrome; - Quality of life; - Length of stay; - Heparin-induced thrombocytopenia; - Allergic reaction; - Mechanical device complications; - Infections | - Symptomatic DVT; - Symptomatic PE; - Asymptomatic DVT; - Bleeding; - Mortality; - Post-thrombotic syndrome; - Quality of life; - Length of stay; - Heparin-induced thrombocytopenia; - Allergic reaction; - Mechanical device complications; - Infections | - Symptomatic DVT; - Symptomatic PE; - Asymptomatic DVT; - Bleeding; - Mortality; - INR, PTT, Factor Xa level (KQs 7and 8); - Post-thrombotic syndrome; - Quality of life; - Length of stay; - Bleeding (major, minor); - Heparin-induced thrombocytopenia; - Allergic reaction; - Mechanical device complications; - Infections
Adverse effects of intervention(s) and treatment burden | - Major bleeding defined as including: fatal bleeding; clinically overt bleeding causing a fall in hemoglobin of ≥2 g/dL or leading to transfusion of two or more units of packed cells or whole blood; or bleeding into critical organs (retroperitoneal or intracranial); In surgical patients: an assessment of the amount of blood loss, minor bleeding, surgical site bleeding, and complications from mechanical IVC filters (e.g., device migration, perforation, fractures, filter thrombosis, infections, prolonged hospitalization, mortality)
Timings | - Studies with all durations of followup
Settings | - Hospital setting | - Hospital setting | - Hospital setting | - Hospital setting | - Hospital setting

DVT = deep vein thrombosis; INR = international normalized ratio; IVC = inferior vena cava; KQ = Key Question; LMWH = low-molecular-weight heparin; PE = pulmonary embolism; PTT = partial thromboplastin time; SCD = sequential circumferential compression device; UFH = unfractionated heparin

## Data Abstraction and Data Management

We used DistillerSR (Evidence Partners, 2010) to manage the screening and review process. DistillerSR is a Web-based database management program that manages all levels of the review process.

Two independent reviewers conducted title scans. For a title to be eliminated at this level, both reviewers had to indicate that the study was ineligible. If the reviewers disagreed, we advanced the article to the next level, abstract review. Two investigators independently reviewed abstracts and we excluded the abstracts if both investigators agreed that the article meets one or more of the exclusion criteria. We tracked and resolved differences between investigators regarding abstract inclusion or exclusion through consensus adjudication. Articles promoted on the basis of abstract review had an independent parallel review to determine if they should be included in review. We resolved the differences by consensus adjudication.

We created standardized forms for data extraction (Appendix C). We pilot tested the forms prior to the beginning the process of data extraction. Each article had double review by study investigators for data abstraction. The second reviewer confirmed the first reviewer's data abstraction for completeness and accuracy. Reviewer pairs included personnel with both clinical and methodological expertise. We tracked and resolved differences between investigators regarding data through consensus adjudication. A third reviewer audited a random sample of articles selected by the first two reviewers to ensure consistency in the abstraction of data from the articles. We did not mask reviewers from the authors, institution, or journal for each article.

Reviewers extracted information on general study characteristics, study participants, eligibility criteria, interventions, outcome measures, the method of ascertainment, and the outcomes, including measures of variability where available. We entered all information from the article review process into the DistillerSR database. We used the DistillerSR database maintain the data, which we then exported into Excel for the preparation of evidence tables.

## Assessment of Methodological Quality of Individual Studies

We conducted the risk of bias independently and in duplicate. This was done independently by two reviewers. Disagreements between the two reviewers were resolved through consensus and adjudication by a third reviewer.

Although the original protocol planned to use different tools for trials and observational studies in the protocol, we chose a single instrument the Downs and Black instrument (Appendix E).46 The need to standardize the rating of risk of bias across heterogeneous study designs including case reports, case-series, uncontrolled cohort studies, case-control studies, prospective and retrospective cohort studies and randomized trials prompted this change. We categorized the trials as having low risk of bias, moderate risk of bias, or high risk of bias and observational studies as having moderate risk of bias and high risk of bias.

We found that 10 items were most relevant to this review and we prioritized them in our assessment of risk of bias. We considered studies to have a low risk of bias if all of the following were true: the article completely described the hypothesis, the outcomes (in the introduction or methods section), the characteristics of the included subjects, the distribution of the potential confounders in each group, the interventions and comparisons (if relevant), the main findings, adverse events, and characteristics of the subjects lost to followup. Additionally, we judged studies to be at low risk of bias if they randomized subjects to the intervention and concealed the assignment until randomization was complete, and if they attempted to blind the study participants and to blind those who measured the main outcomes. By this system, we could not consider any study without randomization to have a low risk of bias. Such nonrandomized studies could only be at moderate or high risk of bias. We rated studies as having a moderate risk of bias if one of those items was not true, even if all of the others were true, or if the reporting on the distribution of potential confounders in each group was at least partially done. If we found two of the elements were not true, we considered the study to have a high risk of bias

Low risk of bias studies had the least bias and the results were considered valid. Moderate risk of bias studies was susceptible to some bias, but not enough to invalidate the results. They did not meet all the criteria required for a rating of good quality because they had some deficiencies. High risk of bias studies had significant flaws that might have invalidated the results.

## Data Synthesis and Analysis

For each KQ, we created a detailed set of evidence tables containing all information abstracted from eligible studies. We grouped the information for each KQ by comparison interventions. We conducted narrative synthesis of the evidence since the population, intervention and outcome characteristics across studies were heterogeneous. For studies amenable to pooling with meta-analysis we conducted meta-analysis using relative risks by using a DerSimonian and Laird Random effects model.47 We identified substantial statistical heterogeneity in the trials as an I-squared statistic with a value greater than 50 percent. Since most of the outcomes were rare and several studies had zero events, with an imbalance in treatment arms we used the treatment arm continuity correction approach to estimate the relative risk.48 We conducted sensitivity analysis using alternative continuity corrections (0.5, 0.1) as well as no continuity correction (Peto Odds Ratio). All analyses were conducted using Stats Direct and Stata version 11.0.^48^ For KQ 1, we calculated 95% exact binomial confidence intervals surrounding the proportions of patients experiencing events in each of the observational studies. These were plotted ordered by the year of the study with the size of the box representing the number of individuals in the denominator.

## Grading the Evidence for Each Key Question

After synthesizing the evidence, two reviewers graded the quantity, quality, and consistency of the best available evidence addressing KQs 1 to 8 by adapting an evidence grading scheme recommended in the “Methods Guide for Conducting Comparative Effectiveness Reviews.”49 In assigning evidence grades, we considered the four recommended domains, including risk of bias in the included studies, directness of the evidence, consistency across studies, and precision of the pooled estimate or the individual study estimates. We were unable to assess for publication bias or selective outcomes reporting because the tests for publication bias were underpowered when the number of studies is low (<10).

The risk of bias for an individual study was derived from the algorithm described above. We assessed the aggregate risk of bias of studies and integrated these assessments into a qualitative assessment of the summary risk of bias score. Since the majority of studies in our evidence based were at high risk of bias, most aggregate scores resulted in a high risk of bias rating. A small minority of trials were rated as low to moderate risk of bias.

Precision of individual studies was assessed by evaluating the statistical significance of a comparison. We found that few of the studies reported effect sizes and 95% confidence intervals. We estimated the confidence intervals for some of the outcomes, and also visually examined the Forest plots to assess precision for certain outcomes. We also examined the summary estimates to assess precision for certain outcomes when meta-analysis was possible. If all studies in an evidence base were precise then the evidence base was rated to be precise. Studies whose effect size overlapped with the line of no difference were designated as imprecise. When studies did not report measures of dispersion or variability we rated the precision as unknown.

We rated the evidence as being direct if the intervention was directly linked to the patient oriented outcomes of interest in our analytic framework. We rated the evidence as indirect for intermediate outcomes (anti-Xa) when direct evidence linking the intervention to the ultimate health outcome was lacking.

We used an algorithm for assigning consistency based on the number of studies with similar directions of effect. If all the studies in an evidence base showed a similar direction of effect, we rated the evidence base as consistent. Single studies were rated as having unknown consistency.

To incorporate multiple domains into an overall grade to the strength of the body of evidence we used the estimate of the summary risk of bias score, directness, and consistency along with precision to provide support for an intervention. We used a qualitative approach to incorporating these multiple domains into an overall grade. Since the majority of observational studies were at high risk of bias, we initially assigned a low strength of evidence for outcomes from such studies. Consistent, precise and direct evidence from such high risk of bias studies was rated as low strength of evidence. The strength of evidence was downgraded to insufficient when consistency was unknown (i.e. single study) or inconsistent. The strength of evidence was downgraded to insufficient when evidence was indirect. Imprecision or unknown precision also led to a downgrade in the strength of evidence from low to insufficient. We also had a small minority of trials that were at low or moderate risk of bias in the updated search. Evidence from such studies was initially assigned a high or moderate strength of evidence based on the risk of bias ratings. Each further weakness in the SOE domain, such as indirectness, imprecision or inconsistency led to a further downgrade in their SOE ratings. A single study of high or moderate risk of bias was considered insufficient evidence.We classified evidence pertaining to KQs 1 to 8 into four categories: (1) “high” grade (indicating high confidence that the evidence reflects the true effect, and further research is very unlikely to change our confidence in the estimate of the effect); (2) “moderate” grade (indicating moderate confidence that the evidence reflects the true effect, and further research may change our confidence in the estimate of the effect and may change the estimate); (3) “low” grade (indicating low confidence that the evidence reflects the true effect, and further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate); and (4) “insufficient” grade (evidence is not sufficient to draw a conclusion).

## Assessing Applicability

Two reviewers assessed applicability separately for the outcomes of benefit (reduction in VTE) and harm (increased risk of bleeding) for the entire body of evidence guided by the PICOTS framework as recommended in the “Methods Guide for Comparative Effectiveness Reviews.”49 We evaluated whether the include populations in these studies were representative of participants in the real world. We assessed whether the concomitant interventions administered in these studies were also representative of real world management strategies for these special populations. We assessed whether there were features of the individuals studies which limited the applicability of the study's findings including whether studies excluded patients with comorbidities, whether studies allowed or disallowed the concomitant use of nonmedical co-interventions (early ambulation), and the choice and dosing of comparators. We assessed whether findings were applicable to various ethnic groups.

### Peer Review and Public Comment

A full draft report was reviewed by experts and posted for public commentary from August 2, 2012, through August 30, 2012. Comments received from either invited reviewers or through the public comment website were compiled and addressed. A disposition of comments will be posted on the Effective Health Care Program Web site 3 months after the release of the evidence report.