# Introduction

## Background

Pulmonary embolism (PE) resulting from deep vein thrombosis (DVT), collectively known as venous thromboembolism (VTE), affects an estimated 900,000 Americans every year, resulting in significant morbidity and mortality.1,2 Although the average annual incidence of DVT currently ranges from 48 to 122 per 100,000 in the United States, 1,2 rates will likely rise along with the country's aging population. There are significant adverse consequences of DVT and PE1, including an estimated 300,000 fatalities annually, and hundreds of thousands of hospitalizations in nonfatal cases.1,2 In addition, a diagnosis of DVT or PE in the hospital increases the costs of index hospitalization by approximately $10,000 and $20,000, respectively.3 Thus, VTE is an important patient safety issue with significant morbidity, mortality, and health care costs.4 Accordingly, the comparative effectiveness and safety of interventions for the prevention and treatment of VTE are among the national priorities for comparative effectiveness research.5 In this review, we describe the evidence about prevention of DVT in “special populations,” which we define below. For most of these populations, there are no guidelines that provide recommendations regarding care. Additionally, for most, there is considerable decisional uncertainty about the best option for thromboprophylaxis. The results of this comparative effectiveness review will inform those developing guidelines, and clinicians and patients who are making decisions about the best approach to prophylaxis.

Special populations include those patients for whom the benefit or risk of VTE prophylaxis is uncertain, or patients for whom there is decisional uncertainty about the optimal choice, timing, and dose of VTE prophylaxis, or significant practice variation. The burden of VTE is higher among some patient populations including patients who have experienced recent trauma6-11 or burns;12-14 patients undergoing bariatric surgery;15-21 and patients with acute renal failure, chronic renal failure, or end-stage renal disease.22-25 Not only do these patients have an increased risk of DVT and PE, but most are also at high risk for bleeding, the most important complication of VTE prophylaxis. Therefore, the risk-benefit ratio of prophylactic medications in these populations is uncertain, and is similarly unclear in populations of patients with altered clearance of medications.26-30

## Special Populations

### General Traumatic Injury

Trauma is known to be a major risk factor for VTE. A prospective study reported rates of DVT as high as 58 percent among those who experienced severe trauma (injury severity score >9) without thromboprophylaxis.6 Among hospitalized trauma patients, PE occurs in one of every 25 patients and studies have linked PE to considerable mortality.6 Some patients with special types of trauma, such as those with spinal trauma, are at the highest risk of DVT, with rates approximating 80 percent.4 There appear to be significant practice variation and clinical uncertainty around the role of pharmacologic versus mechanical prophylaxis among patients with trauma. Although clinicians commonly recommend pharmacologic prophylaxis, some may consider it to be contraindicated in certain trauma patients, such as those with: solid organ injury (i.e., liver, spleen, or kidney); pelvic or retroperitoneal hematoma; ocular injury with hemorrhage; or thrombocytopenia (platelet count <50,000). In these cases, there is debate about the placement of prophylactic inferior vena cava (IVC) filters to prevent PE. Some authors suggest that using this intervention among patients at very high risk may prevent the most dramatic and life-threatening cases of PE, although evidence for this is uncertain. Other studies associate IVC filters with significant complications,31,32 such as the occurrence of DVT,57 and recommend against their use. Other studies show that placement of IVC filters do not lower the rate of PE and may not be of benefit in the trauma setting34 or among other patient populations.34 Ongoing uncertainty exists about whether clinicians should use prophylactic IVC filters in trauma patients for whom anticoagulation is relatively contraindicated. The concept of temporary (also known as “retrievable” or “optional”) IVC filters is appealing but further complicates the picture. Current guidelines from the American College of Chest Physicians (ACCP) recommend against the use of IVC filters for primary prevention in patients without proven VTE.4 The Eastern Association for the Surgery of Trauma guidelines suggest that clinicians can consider using prophylactic IVC filters in patients who have certain significant injury patterns, are at very high risk for VTE, and cannot receive pharmacologic prophylaxis.35

### Patients With Traumatic Brain Injury

There is considerable practice variation and clinical uncertainty about the choice of a prophylaxis modality (pharmacologic or mechanical), and about the optimal pharmacologic agent, dose, timing of initiation, and duration among patients with traumatic brain injury.36 This population has an increased risk for VTE due to a combination of factors (i.e., the brain injury itself, other injuries, intensive care unit admission, immobilization, major surgery, etc.). This risk should prompt routine thromboprophylaxis; however, the associated elevated risk of bleeding in patients with traumatic brain injury often leads physicians to withhold anticoagulant thromboprophylaxis. The concern about anticoagulant thromboprophylaxis in this population is progression of intracranial bleeding that may result in clinical deterioration and possibly worse long-term outcomes. There is ongoing clinical uncertainty and wide variations in practice regarding the appropriate time to initiate pharmacologic prophylaxis.

### Patients With Burns

Patients hospitalized with burns are at an increased risk for VTE, but there is no consensus about the most appropriate prophylactic strategy for prophylaxis of VTE among these patients.37 DVT has a reported incidence of 1 to 23 percent in a series of burn patients.14 The ACCP guidelines recommend thromboprophylaxis if possible for burn patients who have additional risk factors for VTE such as advanced age, morbid obesity, extensive burns, burns to the lower extremities, concomitant trauma to the lower extremities, use of a femoral venous catheter, and/or prolonged immobility (Grade 1C).4 However, concerns about the potential risk of heparin-associated bleeding may have resulted in very low rates of heparin use and considerable uncertainty about the optimal choice of therapy among burn centers.13 There is considerable uncertainty around specific drugs, dosing regimens, and the risk-benefit tradeoff for these particular subpopulations of patients.

### Patients With Liver Disease

Patients with liver diseases such as cirrhosis may be simultaneously at increased risk for both bleeding and thrombosis, thus complicating the decisions related to VTE prevention.38 Patients with thrombocytopenia, platelet dysfunction, and a prolonged international normalized ratio (INR), secondary to liver disease, are at increased risk for both minor and major bleeding secondary to altered hemostasis.39 However, patients with these specific conditions often remain at risk for venous thromboembolism, particularly since many of the illnesses that lead to defects in hemostasis—such as cirrhosis—can directly precipitate thrombosis as a result of activated hemostasis and may also precipitate thrombosis indirectly through complications such as infection. There is clinical uncertainty about the optimal choice of VTE prophylaxis in this patient population and about the optimal threshold of thrombocytopenia and the prolonged INR value at which bleeding increases with anticoagulant thromboprophylaxis. There are no specific reviews or guidance documents that clarify the role of thromboprophylaxis in these patients.

### Individuals Receiving Antiplatelet Therapy

Patients receiving antiplatelet therapy with acetylsalicylic acid or thienopyridines, such as clopidogrel, ticlopidine, and prasugrel, are at increased risk for bleeding. These patients constitute a large proportion of patients hospitalized for various medical conditions.38 There is clinical uncertainty about the optimal choice of VTE prophylaxis in this patient population. There are no specific guidance documents that clarify the role of thromboprophylaxis in patients receiving chronic long term antiplatelet therapy.

### Individuals Having Bariatric Surgery

There is clinical uncertainty about venous thromboprophylaxis is patients who undergo bariatric surgery. In an analysis of a large cohort in the Bariatric Outcomes Longitudinal Database,20 the incidence of VTE after bariatric surgery was 0.42 percent within 90 days after surgery. Although these obese patients were at risk of VTE, their hospitalizations were short, and they were able to ambulate early. The risk of VTE was greater in the patients who underwent gastric bypass than in those who underwent adjustable gastric banding (0.55 vs. 0.16 percent). The risk of VTE was also greater in patients who had an IVC filter placed (hazard ratio 7.7; 95% confidence interval 4.5–13). The ACCP guidelines recommend low dose unfractionated heparin (UFH) and low-molecular-weight heparins (LMWH) or fondaparinux at higher than usual doses for patients undergoing bariatric surgery.4 A recent survey of bariatric surgeons reported that nearly 60 percent of bariatric surgeons preferred LMWH for prophylaxis.15 However, many were uncertain about the best choice of therapy and about the timing and duration of VTE prophylaxis.15 Therefore, there is much practice variation, ranging from no prophylaxis to multimodality thromboprophylaxis that might also include preoperative placement of an IVC filter.

### Obese or Underweight Hospitalized Patients

Studies associate obesity, including severe obesity, with an increased risk of VTE.40 It is uncertain if fixed doses of pharmacologic agents such as UFH, LMWH, and factor Xa inhibitors provide optimal prophylaxis in this special population. The pharmacokinetics of several agents may be different among obese patients requiring dose adjustments.41 Although LMWH and other pharmacologic agents may require dosage adjustments, the optimal dosing strategy (including duration of therapy) for these patients is not clear. Similarly, the optimal choice and dosing regimens for patients who are underweight (body mass index <18.5 kg/m^2^) is unclear.

### Patients With Acute or Chronic Renal Failure

The optimal treatment choice and dosing strategy for thromboprophylaxis for patients with acute or chronic renal failure and chronic kidney disease (CKD) remains uncertain. In a prospective community-based cohort, patients with stage 3 or 4 CKD had a higher risk of VTE than those with normal kidney function.22 The rates of VTE among patients with end-stage renal disease were also high. Generally, the burden of VTE among patients with CKD falls disproportionately on Hispanics and African Americans.42 Patients with advanced CKD also have a tendency to bleed because of platelet dysfunction.43 Fondaparinux and LMWHs are primarily eliminated via the renal pathway and may accumulate in patients with renal failure. This accumulation is dependent in part on the chain lengths of the LMWHs and their subsequent renal clearance, thereby resulting in different pharmacokinetic and pharmacodynamics effects.30 Consequently, patients with diminished renal function may be at an increased risk for bleeding. Although there appear to be differences between the LMWHs with regard to accumulation risk, the relationship between their use and the incidence of bleeding is not well established. ACCP guidelines recommend that clinicians should dose adjust, monitor, or simple avoid anticoagulant medications that bioaccumulate (Grade 1C). Cook et al.,25 argued that LMWHs may be the optimal choice, given the lower incidence of thrombocytopenia in patients with CKD. There are similar concerns about the optimal strategies for VTE prophylaxis among patients with acute kidney injury.

## Therapies of Interest

In this review, we describe the evidence for drugs and devices that currently are available in the United States and that are either FDA approved for VTE prophylaxis or that clinicians may use without an indication (“off-label”) for this purpose (Table 1).

Table 1 Pharmacologic agents and medical devices approved in the United States for some indication and that may be considered for VTE prophylaxis

Pharmacologic Agent | Intervention | Route | Dose | Manufacturer | U.S. Availability | Comments
Antiplatelets | Aspirin | Oral | Various | Various | Yes | NA
Antiplatelets | Clopidogrel (Plavix^®^) | Oral | 75 or 300 mg base | Sanofi Aventis/Bristol-Myers Squibb | Yes | NA
Antiplatelets | Ticlopidine (Ticlid^®^) | Oral | 125 or 250 mg | Hoffman-La Roche Inc. | | NA
Antiplatelets | Prasugrel (Effient^®^) | Oral | EQ 5 or 10 mg base | Roche Palo | Yes | NA
Antiplatelets | Ticagrelor (Brilinta^®^) | Oral | 90 mg | AstraZeneca LP | Yes | NA
Antiplatelets | Dipyridamole (Persantine^®^) | Oral | 25, 50, or 75 mg | Boehringer Ingelheim | Yes | NA
Antiplatelets | Cilostazol (Pletal^®^) | Oral | 50 or 100 mg | Otsuka | Yes | NA
Dextran sulphate | Dextran sulphate | Intravenous | Various | PKC | Yes | NA
Vitamin K Antagonists | Warfarin (Coumadin^®^) | Oral | 1–10 mg | Various generics; Bristol-Myers Squibb | Yes | NA
Vitamin K Antagonists | Dicumarol | Oral | Various
Low-Dose Unfractionated Heparins | Heparin | Subcutaneous | 5,000 Units BID or TID | Several | Yes | NA
Low-Molecular-Weight Heparins | Enoxaparin sodium (Lovenox^®^) | Subcutaneous | 40 mg QD or 30 mg BID (30 mg for renal impairment) | Sanofi-Aventis; generic from Sandoz (2010) | 1993 | Dosing indication for abdominal surgery and acutely ill medical patients
Low-Molecular-Weight Heparins | Dalteparin sodium (Fragmin^®^) | Subcutaneous | 5,000 IU QD | Eisai/Pfizer | 1994 | Indicated for surgery prophylaxis
Low-Molecular-Weight Heparins | Tinzaparin sodium (Innohep^®^) | Subcutaneous | 3,500 IU QD to 4,500 IU SC daily | LEO Pharma/Celgene | 2000 | Indicated for surgery prophylaxis
Factor Xa Inhibitors | Fondaparinux (Arixtra^®^) | Subcutaneous | 2.5 mg QD | GSK | 2001 | Indicated for abdominal surgery prophylaxis
Factor Xa Inhibitors | Rivaroxaban (Xarelto^®^) | Oral | 10 mg QD | Johnson and Johnson | 2011 | Indicated for elective hip/knee arthroplasty
Direct Thrombin Inhibitors | Argatroban (Argatroban^®^) | Intravenous Infusion | 100 mg/mL | Pfizer | 2000 | Prophylaxis with active HIT
Direct Thrombin Inhibitors | Dabigatran (Pradaxa^®^) | Oral | 75 and 150 mg | Boehringer Ingelheim | 2010 | Prevent stroke and systemic embolism in AF
Direct Thrombin Inhibitors | Bivalirudin (Angiomax^®^) | Intravenous | 250 mg/Vial | The Medicines Company | 2000 | NA
Direct Thrombin Inhibitors | Lepirudin (Refludin^®^) | Intravenous Infusion | 50 mg/Vial | Bayer | 1998 | Anticoagulation with HIT to prevent further thromboembolic complications

Mechanical Device | Intervention | Name | Manufacturer | Comments
| Intermittent Pneumatic compression | Aircast VenaFlow | DJO | Apply intermittent application of pressure to a patient's calf, thigh or foot for the purpose of assisting blood flow in the veins.
| Intermittent Pneumatic compression | SCD Express | Tyco/Kendall | DVT prophylaxis
| Graduated compression stockings | Jobst T.E.D.^®^ Others | Jobst | To prevent pooling of blood in legs
| Venous Foot Pumps | A-V Impulse System Venodyne | Novamedix | DVT prophylaxis
Inferior Vena Caval Filters | Name | Type | Manufacturer | Comments
| Greenfield Stainless Steel^®^ | Permanent | Boston Scientific | Prevention of PE with venous thrombosis or pulmonary thromboembolism when anticoagulants are contraindicated
| Simon Nitinol^®^ | Permanent | Bard Peripheral Vascular | Preventing PE from migrating to the pulmonary arteries
| TRAPEASE^®^ | Permanent | Cordis | Prevention of recurrent PE when anticoagulants are contraindicated
| Greenfield Titanium^®^ | Permanent | Boston Scientific | No information available
| Vena Tech LP^®^ | Permanent | B. Braun | Partial interruption of IVC to prevent PE when anticoagulants are contraindicated
| Gianturco-Roehm Bird's Nest^®^ | Permanent | Cook | Prevention of recurrent PE when anticoagulants are contraindicated
| Celect^®^ | Retrievable | Cook | Prevention of recurrent PE when anticoagulants are contraindicated
| Gunther Tulip^®^ | Retrievable | Cook | Prevention of recurrent PE when anticoagulants are contraindicated
| G2^®^ | Retrievable | Bard Peripheral Vascular | Prevention of recurrent PE
| G2x^®^ | Retrievable | Bard Peripheral Vascular | Prevention of recurrent PE when anticoagulants are contraindicated
| Eclipse^®^ | Retrievable | Bard Peripheral Vascular | Prevention of recurrent PE when anticoagulants are contraindicated
| VenaTech LGM^®^ | No longer sold | B. Braun | Partial interruption of IVC to prevent PE when anticoagulants are contraindicated
| Tempofilter^®^ | Retrievable | B. Braun | NA
| ALN IVC^®^ | Retrievable | ALN Implants | Prevention of recurrent PE when anticoagulants are contraindicated
| Option IVC^®^ | Retrievable | Rex/Angio Tech | Prevention of recurrent PE when anticoagulants are contraindicated
| Safeflo^®^ | Permanent | Rafael Medical | Prevention of recurrent PE when anticoagulants are contraindicated
| OPTEASE^®^ | Retrievable | Cordis Corp | Prevention of recurrent PE when anticoagulants are contraindicated

AF = atrial fibrillation; BID = twice a day; DVT = deep vein thrombosis; EQ = equivalent; HIT = heparin-induced thrombocytopenia; IU = international unit; IVC = inferior vena cava; PE = pulmonary embolism; QD = once a day; SC = subcutaneous; TID = three times a day

The pharmacologic agents of interest include UFH and LMWH delivered subcutaneously.26-29 The anticoagulant action of unfractionated heparin occurs due to binding to antithrombin, and resulting inactivation of Factor IIa, Xa, IXa, XIa, XIIa.44 Low molecular weight heparins primarily promote Factor Xa inhibition.44 Fondaparinux, a synthetic pentasaccharide, is also available as an option for thromboprophylaxis. We also included dabigatran, a recently approved oral anticoagulant that directly inhibits thrombin; the FDA approved it for the prevention of stroke in patients with atrial fibrillation, but it has the potential for off-label use for prophylaxis of VTE. Rivaroxaban is an oral factor Xa inhibitor that the FDA approved in July 2011 for VTE prophylaxis for patients undergoing elective hip and knee arthroplasty; this drug also has the potential for off-label use in other patient populations. Similarly, we included antiplatelet agents, such as aspirin and clopidogrel, as well as the anticoagulant warfarin, which clinicians may use off-label for this indication.

We also included sequential compression devices, venous foot pumps, and various types of IVC filters, in this review.4 They are all devices that clinicians use for VTE prophylaxis.

## Key Questions

This report includes our review of the evidence about the efficacy, effectiveness, and safety of pharmacological and mechanical methods of prophylaxis in our defined special populations. The Key Questions (KQs) we explored are as follows:

KQ 1. What are the comparative effectiveness and safety of IVC filters to prevent PE in hospitalized patients with trauma?

KQ 2. What are the comparative effectiveness and safety of pharmacologic and mechanical strategies to prevent VTE in hospitalized patients with traumatic brain injury? What is the optimal timing of initiation and duration of pharmacologic prophylaxis to prevent VTE in hospitalized patients with traumatic brain injury?

KQ 3. What are the comparative effectiveness and safety of pharmacologic and mechanical strategies to prevent VTE in hospitalized patients with burns?

KQ 4. What are the comparative effectiveness and safety of pharmacologic and mechanical strategies to prevent VTE in hospitalized patients with liver disease?

KQ 5. What are the comparative effectiveness and safety of pharmacologic and mechanical strategies to prevent VTE in hospitalized patients receiving antiplatelet therapy?

KQ 6. What are the comparative effectiveness and safety of pharmacologic and mechanical strategies to prevent VTE in patients having bariatric surgery?

KQ 7. What are the comparative effectiveness and safety of pharmacologic prophylaxis for prevention of VTE during hospitalization of obese and underweight patients?

KQ 8. What are the comparative effectiveness and safety of pharmacologic prophylaxis for prevention of VTE during hospitalization of patients with acute kidney injury, moderate renal impairment, or severe renal impairment not undergoing dialysis and patients receiving dialysis?

## Framework

Figure 1 presents the analytic framework for this systematic review. It illustrates the KQs, special populations of interest, therapies, and intermediate and clinical outcomes included in our review, as well as the adverse consequences associated with the specified prophylactic regimens.

Figure 1 Analytic framework: Pharmacologic and mechanical prophylaxis of venous thromboembolism among special populations

INR = international normalized ratio; IVC = inferior vena cava; KQ = Key Question; PTT = partial thromboplastin time

Figure 1 is our analytic framework, presenting the Key Questions (KQ) in terms of the following hospitalized populations: trauma, burns, thrombocytopenia and/or , prolonged international normalized ratio secondary to liver disease, patients on antiplatelet agents, bariatric surgery, obese and underweight, acute kidney injury, moderate renal impairment, severe renal impairment, and renal replacement therapy. Interventions listed in the framework include: unfractionated heparin (UFH), low-molecular-weight heparin (LMWH), factor Xa inhibitors, direct thrombin inhibitors (DTI), mechanical devices, and inferior vena cava (IVC) filters. The framework also includes adverse effects of interventions: bleeding (major, minor), heparin-induced thrombocytopenia (HIT), allergic reaction, mechanical device complications, and infections. Intermediate outcomes are listed as: Asymptomatic deep vein thrombosis (DVT), and INR, PTT, and factor Xa level. Also presented are patient-oriented outcomes: symptomatic DVT, symptomatic pulmonary embolism (PE), mortality, post thrombotic syndrome, quality of life, length of hospital stay, and hospital visit.