# Peer Reviewers

- Nancy Birkmeyer, Ph.D.
  University of Michigan Health Systems
  Ann Arbor, MI
- Mark Crowther, M.D. M.Sc., FRCPC
  McMaster University
  Hamilton, ON, Canada
- Lee Faucher, M.D.
  University of Wisconsin School of Medicine and Public Health
  Madison, WI
- David Allen Garcia, M.D.
  University of New Mexico
  Albuquerque, NM
- Oscar Guillarmondegui, M.D.
  Vanderbilt University
  Nashville, TN
- Andrew Kerwin, M.D., FACS
  University of Florida
  Jacksonville, FL
- Geno Merli, M.D.
  Jefferson University Hospitals
  Philadelphia, PA
- Sankar Navaneethan, M.D.
  Cleveland Clinic
  Cleveland, OH
- Suresh Vendantham, M.D.
  Washington University School of Medicine
  St. Louis, MO
- Daniel Yeh, Ph.D.
  University of South Florida
  Tampa, FL