# Technical Expert Panel

- Jack Ansell, M.D.
  Lenox Hill Hospital
  New York, NY
- William Geerts, M.D.
  University of Toronto
  Toronto, ON
- Oscar Guillamondegui, M.D.
  Vanderbilt School of Medicine
  Nashville, TN
- Stuart T. Haines, Pharm.D., FCCP, FASHP, FAPhA
  University of Maryland School of Pharmacy
  Baltimore, MD
- Gregory Maynard, M.D., M.SC.
  University of California, San Diego
  San Diego, CA
- Steven Shackford, M.D., FACS
  University of California, Davis
  Davis, CA
- Michael Streiff, M.D.
  Johns Hopkins School of Medicine
  Baltimore, MD
- Richard H. White, M.D.
  University of California, Davis
  Davis, CA
- Steven E. Wolf, M.D., FACS
  University of Texas Health Science Center
  San Antonio, TX