# Key Informants

- James Bush, M.D.
  Wyoming Department of Health
  Cheyenne, WY
- Mark Cipolle, M.D., Ph.D., FACS, FCCM
  Eastern Association for the Surgery of Trauma (EAST)
  Newark, DE
- Bruce Davidson, M.D., FCCP
  American College of Chest Physicians
  Burien, WA
- Charles Francis, M.D.
  University of Rochester
  Rochester, NY
- Stuart T. Haines, Pharm.D., FCCP, FASHP, FAPhA
  University of Maryland School of Pharmacy
  Baltimore, MD
- James Holmes, M.D.
  Wake Forest University
  Winston-Salem, NC
- Thomas Magnuson, M.D.,
  Johns Hopkins School of Medicine
  Baltimore, MD
- Gregory Maynard, M.D., M.SC.
  University of California, San Diego
  San Diego, CA
- Mary Ellen McCann, R.N., M.A.
  National Blood Clot Alliance
  Tarrytown, NY