# Acknowledgments

The authors gratefully acknowledge the continuing support of our AHRQ Task Order Officer, Supriya Janakiraman, M.D. We extend our appreciation to our Key Informants and members of our Technical Expert Panel (listed below), all of whom provided thoughtful advice and input during our research process.

The EPC thanks Oluwatosin Ikotun, Carmelasophia L. Magalona, Nelson Biodun Olagbuji, and Shauna T. Linn for their assistance with data abstraction and Manisha Reuben for her assistance with the final assemble and formatting of this report.