# Discussion

Our systematic review summarizes the current state of the evidence on the role of pharmacologic and mechanical prophylaxis for the prevention of VTE among these special populations. Our review demonstrates a paucity of evidence from high quality studies to inform these Key Questions for these special populations.

## Evidence

### Key Question 1 What are the comparative effectiveness and safety of IVC filters to prevent PE in hospitalized patients with trauma?

The strength of evidence is low that prophylactic IVC filter placement when compared with no filter use is associated with a lower incidence of PE and fatal PE in hospitalized patients with trauma. We also found insufficient evidence that prophylactic IVC filter placement is associated with an increased incidence of DVT in hospitalized patients with trauma when compared with no use of filters. We found insufficient evidence to comment on mortality associated with prophylactic IVC filter placement in hospitalized patients with trauma.

We noted the different filter brands may be associated with different complications but we did not have enough comparisons among different filter subtypes to evaluate the comparative effectiveness and safety of various filter subtypes.

We found insufficient evidence from the comparative observational studies that rates of filter- associated thrombosis were higher when prophylactic filters were placed compared with not in this patient population. The evidence was insufficient about rates of other filter complications. Several uncontrolled observational studies provided information on the rare occurrences of filter complications such as strut fracture, insertion site thrombosis, arterial-venous fistulas, filter misplacement, filter tilt, filter migration and IVC thrombosis. The low rates of such complications, the significant risks of bias in the included studies, and the lack of control groups precluded any definitive assessment of the comparative safety of different filter types in patients with trauma. Our review did not evaluate the safety of IVC filters in patients when used for treatment or prevention of recurrent PE where complication rates may be different.

We identified only a single RCT addressing this KQ and it had significant methodological limitations.52 This pilot trial randomized patients to usual care plus IVC filters versus usual care but was underpowered for all outcomes. Most studies in our database were assessed as having a high risk of bias except five observational studies which were assessed as having a moderate risk of bias. There was significant heterogeneity among the included studies in design and eligibility, and inconsistency in efficacy and safety outcome assessment methods. Although many of the studies reported on the VTE outcomes, most did not provide details about anatomic locations of the DVTs or PEs. Some studies did not distinguish between DVT and PE. However prophylactic IVC filters may have opposing effects on DVTs and PEs, increasing the rates of DVTs and reducing the risk of PE. There were also differences in reporting and duration of follow-up. The included studies lacked adequate details about enrolled patient characteristics, such as race and gender, and details of the extent and severity of the trauma limiting our ability to generalize findings from these studies to other ethnic groups or age categories. There has been a wide variation in the use of IVCFs in trauma centers which cannot be explained by patient characteristics.158 This variation could lead to selection bias for any observational studies of IVCFs.

Our current finding should be interpreted in the context of other systematic reviews on this topic. A recent review conducted a qualitative synthesis of data from 24 studies and found increasing use of retrievable filters and low rates of filter related complications.159 The authors concluded that there was a lack of high quality data, and therefore the true efficacy of prophylactic IVC filters for prevention of PE in trauma patients remains unclear. They reported that data from case series suggested a reduction in PE and fatal PE in high-risk poly-trauma patients who may have contraindications to DVT prophylaxis. A review from 2006, endorsed by the American Venous Forum, found that the evidence on optional IVC filters was not sufficient to support evidence-based recommendations.160 Similarly, we only found low grade evidence that IVC filter placement compared with no IVC filter placement is associated with a lower incidence of PE and fatal PE in hospitalized patients with trauma, and insufficient evidence that prophylactic IVC filters placement is associated with an increased incidence of DVT in hospitalized patients with trauma.

There are conflicting guidelines on this topic. The practice guideline from the Eastern Association for the Surgery of Trauma recommends that insertion of a prophylactic IVC filters should be considered in very high risk trauma patients.35 These include patients who cannot receive anticoagulation because of increased bleeding risk and have severe closed head injury (GCS < 8), incomplete spinal cord injury with part or quadriplegia, complex pelvic fractures with associated long-bone fractures, or multiple long-bone fractures (Level 3 recommendation). However, this guideline is 10 years old and was based primarily on data using permanent IVCFs. A recent American College of Chest Physicians (ACCP) review suggested that that placement of an IVC filter probably reduces the risk of PE over the short term, but notes that the complications are “frequent” and long term outcomes are unclear.161 This group noted that removable filters may mitigate the long-term complication rate, but also noted that they are often not removed. Thus the ACCP guidelines recommends against IVC filters for primary VTE prevention in patients with trauma (Grade 2C).161

### Key Question 2a What are the comparative effectiveness and safety of pharmacologic and mechanical strategies to prevent VTE in hospitalized patients with traumatic brain injury?

### Key Question 2b What is the optimal timing of initiation and duration of pharmacologic prophylaxis to prevent VTE in hospitalized patients with traumatic brain injury?

Eight studies evaluated pharmacologic and mechanical strategies in hospitalized patients with traumatic brain injury. We found low grade evidence that UFH reduced the rates of total mortality compared with no pharmacoprophylaxis in hospitalized patients with traumatic brain injury. We also found low grade evidence that enoxaparin reduced the rates of DVT when compared with no pharmacoprophylaxis in traumatic brain injury patients. The strength of evidence is insufficient to comment on the comparative effectiveness and safety of any other pharmacological and mechanical strategies on VTE outcome and bleeding.

There was insufficient evidence to support that enoxaparin is more effective than unfractionated heparin in preventing PE and lowering mortality in hospitalized patients with traumatic brain injury. We also found insufficient evidence to support that enoxaparin when compared with heparin led to fewer bleeding complications. We found insufficient evidence to support that enoxaparin is more effective than intermittent pneumonic compression in preventing DVTs. We found insufficient evidence to support that intermittent pneumatic compression devices are more effective than enoxaparin in preventing PEs.

We found only two RCTs that addressed DVT prophylaxis in patients with traumatic brain injury. The remaining studies were single-center cohort studies, the majority of which were retrospective. Although the studies in this review asked similar questions (i.e., enoxaparin vs. heparin, pharmacologic prophylaxis vs. IPCs) and had similar patient populations, due the lack of high quality studies having minimal risk of bias, we were unable to comment on the comparative effectiveness of pharmacological and mechanical prophylaxis of venous thromboembolism in hospitalized patients with traumatic brain injury.

When looking at progression of ICH, we found insufficient evidence favoring enoxaparin when compared with unfractionated heparin or no use of chemoprophylaxis. When compared with intermittent pneumatic compression, there was insufficient evidence to support that enoxaparin reduces the risk of ICH exacerbation.

Five retrospective cohort studies evaluated the timing of pharmacologic prophylaxis in patients with traumatic brain injury. We found insufficient evidence to support that early (< 72 hours) compared with late administration of enoxaparin (> 72 hours) led to differences in progressions of ICH. The lack of high quality studies precludes definitive conclusions about the timing and initiation of prophylaxis in patients with brain trauma.

Our results should be interpreted in the context of other systematic reviews and existing guidelines. We did not identify any existing systematic reviews about the role of DVT prophylaxis, and its optimal timing and initiation in patients with traumatic brain injury. The two organizations, EAST and the Traumatic Brain Foundation, that provide guidelines for the care of the patients with trauma and patients with traumatic brain injury, respectively, do not make specific recommendations about DVT prophylaxis in these patients. The Eastern Association for the Surgery of Trauma (EAST) practice guidelines address DVT prophylaxis in the general trauma patient but do not make specific recommendations about patients with brain trauma. In 2007, the Brain Foundation Guidelines for the Management of Severe Traumatic Brain Injury found no good quality data to support the use of DVT prophylaxis in TBI patients. They found level III evidence for IPC and chemoprophylaxis, while stating that “there is insufficient evidence to support recommendations regarding the preferred agent, dose, or timing of pharmacologic prophylaxis for deep vein thrombosis.” Additionally, the ACCP guidelines do not specifically address DVT prophylaxis in these patients.

### Key Question 3 What are the comparative effectiveness and safety of pharmacologic and mechanical strategies to prevent VTE in hospitalized patients with burns?

The strength of evidence was insufficient about the comparative effectiveness and safety of pharmacologic and mechanical strategies to prevent VTE in hospitalized patients with burns.

The only included cohort study of IVC filter placement was at high risk of bias with significant methodological limitations. It included just 20 patients and did not have a control group. The very high mortality rate in this study (9 out of 20 participants) was likely related to multi-organ failure. Thus, we could not draw any meaningful conclusions 126 on the comparative effectiveness and safety of IVC filters. We did not find any studies that evaluated the comparative effectiveness and safety of pharmacologic strategies in the prevention of VTE among patients with burns.

There are several unanswered clinical questions for patients with burns. These patients are at elevated risk of both VTE and bleeding and the optimal prophylaxis remains unknown. Although the study we reviewed reported that the burned body surface area was not associated with thrombotic complications,162 this remains unclear.

Clinicians, policymakers, and other decision makers should interpret our findings in the context of existing recommendations for VTE prevention among hospitalized patients with burns. The ACCP 2012 guidelines do not provide specific recommendations for preventing VTE in patients with burns.163 The 2008 ACCP guidelines recommend routine thromboprophylaxis for burn patients having additional risk factors for VTE (Grade 1A).164 The guidelines also recommend either low-dose unfractionated heparin or low molecular weight heparin as soon as it is safe (Grade 1C). For patients at risk of bleeding, the guidelines recommend mechanical thromboprophylaxis with graduate compression stockings and or intermittent pneumatic compression until the bleeding risk decreases (Grade 1A).164

### Key Question 4 What are the comparative effectiveness and safety of pharmacologic and mechanical strategies to prevent VTE in hospitalized patients with liver disease?

We found no studies that directly address the comparative effectiveness and safety of pharmacologic strategies among patients with liver disease. Previous studies have estimated that 0.5 to 6.3 percent of patients with chronic liver disease experience VTE. These studies characterize chronic liver disease as a condition complicated by thrombocytopenia and by prevalent portal vein thrombosis.165 The correlation between international normalized ratio values and VTE risk remains unclear.166

There are no specific recommendations for prophylaxis in patients with chronic liver disease. The specific reasons for the lack of evidence on hospitalized patients with liver disease are unclear, but may include exclusion of such high-risk patients from trials.

### Key Question 5 What are the comparative effectiveness and safety of pharmacologic and mechanical strategies to prevent VTE in hospitalized patients receiving antiplatelet therapy?

We found no studies that directly addressed the comparative effectiveness of pharmacologic strategies among hospitalized patients receiving antiplatelet therapy. However, two large pooled analysis of randomized controlled trials of pharmacoprophylaxis of VTE reported on this KQ.127,128 There was no difference in the risk of bleeding among patients on antiplatelets when dabigatran was compared with enoxaparin, or rivaroxaban was compared with enoxaparin. These drugs were used for a limited duration, and bleeding was recorded within the study time period that did not exceed 30 days. However these findings are not generalizable to patients taking high dose ASA (> 160 mg/day) or those taking other potent antiplatelets such as ticlopidine or clopidogrel, because such patients were not included.

### Key Question 6 What are the comparative effectiveness and safety of pharmacologic and mechanical strategies to prevent VTE in patients having bariatric surgery?

We found low grade evidence to support that IVC filters do not reduce the risk of PE. Other complications of filter placement occasionally occur, some of which may be fatal.147. Only a subset of studies reported on filter retrieval rates. Physicians ultimately removed more than two-thirds of the retrievable filters placed. Because bariatric surgery requires close followup and medical compliance, there may be relatively high rates of filter retrieval in this patient population and a lesser likelihood of long-term filter-related complications. There was marked practice variation in filter use for VTE prophylaxis among hospitalized patients undergoing bariatric surgery, beyond what could be explained by differences in the patient populations. Additionally, the process of selecting patients for filters based on real or perceived VTE risk may bias toward a lack of filter efficacy, or the appearance of harm.149

In the absence of high quality studies, we were unable to determine the comparative effectiveness and safety, or the optimal timing and duration of prophylactic pharmacotherapy. The observational studies did not provide a clear association between the use of pre-operative initiation of pharmacologic prophylaxis and perioperative bleeding, or between post-operative initiation of pharmacologic prophylaxis and thrombosis. A study of extended prophylaxis versus inpatient prophylaxis suggested that continuing enoxaparin therapy for 10 days discharge may be associated with a lower risk of VTE, when compared with shorter therapy.129 However, since this cohort study adopted longer-term treatment during its later years, there were other changes that may have impacted VTE rates favorably, such as shorter surgery durations, fewer open procedures, and shorter lengths of stay, which precludes any definitive conclusions. The rate of fatal pulmonary emboli appears to be low in patients receiving pharmacologic prophylaxis.

Pharmacokinetic data from two studies suggest that “subtherapeutic” anti-Xa levels are common when patients receive standard prophylactic doses of enoxaparin, particularly 30 mg twice daily, and that “supratherapeutic” levels are common when patients receive doses of 60 mg twice daily.132 133 However, the extent to which anti-Xa levels predict bleeding in obese patients undergoing bariatric surgery is unknown. Consistent with current practice, the majority of the studies emphasized the use of IPC devices, compression stockings, and early ambulation. Additionally, the studies that focused on IVC filters generally included patients receiving concurrent pharmacologic prophylaxis. The efficacy and safety of these modalities of prophylaxis remains unclear. One study, not included in our review, reported low rates of adverse outcomes in patients undergoing bariatric surgery who did not receive either IVC filters or pharmacologic prophylaxis.167 This study excluded patients with prior VTE. The study used a prophylactic strategy that included calf-length pneumatic compression devices and early ambulation, and the authors sought to maintain short operative times (averaging 106 minutes). This study, which included 957 patients, reported rates of DVT at 0.31 percent, PE at 0.10 percent, and major bleeding at 0.73 percent. Notable in this study, as well as many studies we included, is that ambulation is often possible within 24 hours of bariatric surgery. The relatively short operative times, laparoscopic approach, and early ambulation may attenuate the VTE risk of laparoscopic bariatric surgeries, despite the large body habitus of those patients undergoing bariatric surgery.

Our results suggest that there may be a higher rate of bleeding with augmented dosing regimens, with no evidence of increased efficacy. These results are generally consistent with the findings from a previous systematic review and meta-analysis conducted by Becattini et al.168 In contrast to our comparative effectiveness review, which evaluated only comparative studies of pharmacologic regimens, Becattini et al. also included uncontrolled single-arm studies of pharmacologic prophylaxis. They concluded that the incidence of symptomatic postoperative VTE appeared to be less than 1 percent with either prophylactic strategy, but that with screening, the rate was approximately 2 percent. Because definitions of major bleeding varied, the authors applied, where possible, the International Society of Thrombosis and Haemostasis definition of major bleeding in an effort to standardize the bleeding rates across studies.169 Using this standardized definition, bleeding rates were approximately 1 percent for standard-dose regimens, and 1.6 percent for weight-adjusted (augmented) pharmacological prophylaxis. The authors concluded that there might be a higher rate of bleeding with augmented dosing regimens with no evidence of increased efficacy similar to our findings.

In the absence of high quality studies among patients undergoing bariatric surgery, the ACCP evidence-based clinical practice guidelines used data from trials in other populations such as patients undergoing abdominal and pelvic surgery.170These guidelines suggest that clinicians follow the manufacturer's recommendations for dosing of pharmacotherapy, but also state that it may be prudent to consult with a pharmacist regarding dosing in bariatric surgery patients and other patients who are obese who may require higher doses of unfractionated heparin or low molecular weight heparin. The guidelines do not make any recommendations regarding the use of filters in bariatric surgery patients.

### Key Question 7 What are the comparative effectiveness and safety of pharmacologic prophylaxis for prevention of VTE during hospitalization of obese and underweight patients?

We found only one subgroup analysis of an RCT that reported on the comparative effectiveness and safety of fixed low-dose dalteparin 5000 IU/day versus placebo among hospitalized obese patients with a BMI less than 40kg/m^2^. However the strength of evidence was insufficient on the composite endpoint of DVT, PE and sudden death; and the outcomes of mortality and bleeding. We did not find any evidence about the role of other pharmacologic or mechanical strategies among hospitalized obese patients. There were no studies among patients who are underweight. Previous ACCP guidelines recommended a weight based administration of low molecular weight heparins among obese patients.164 The FDA-approved dosing provides no specific dose adjustment for obese patients.

The other pertinent study to this Key Question, the Freeman study, although small and not powered to determine clinical efficacy or safety is a pilot study whose findings is consistent with the current ACCP guidelines that recommends the use of weight based administration of low molecular weight heparins in obese patients. The limitations of the study besides its small size include that the primary outcome measured- anti-factor Xa level, is a surrogate marker of adequate anticoagulation and by extension effective prophylaxis against VTE and not the desired clinical outcome itself. Given the median length of stay of 3 days, the outcome was only followed for a maximum of 3 days, and given prior evidence that enoxaparin may accumulate during longer treatment periods (especially in patients with renal impairment) longer periods of follow up will be warranted to give complete picture of the outcome. Finally, the study did not include medically ill but non-obese patients they are not able to exclude that similar findings could be seen in non-obese patients.

### Key Question 8 What are the comparative effectiveness and safety of pharmacologic prophylaxis for prevention of VTE during hospitalization of patients with acute kidney injury, moderate renal impairment, or severe renal impairment not undergoing dialysis and patients receiving dialysis?

Patients with compromised renal function who require pharmacologic VTE prophylaxis are very common. However, we found insufficient evidence in the published literature to guide treatment decisions. The published evidence regarding the relative safety and efficacy of several agents versus enoxaparin are limited to single studies with a moderate-to-high risk of bias. Our findings are consistent with two other recently published reviews. The ACCP guidelines make dosing recommendations for the therapeutic use of LMWH.171 172 However, we agree with the ACCP guidelines' assessment that the data are insufficient to make direct recommendations about prophylaxis. Their assessment of the indirect evidence regarding bioaccumulation and increased anti-Xa levels are also consistent with ours. The ACCP guidelines suggest that decreased clearance of LMWHs has been associated with increased risk of bleeding events for patients with severe renal insufficiency. However, the cited study compares patients with and without severe renal dysfunction who received the same therapy. Therefore, it is not possible to determine the additional risk conveyed by LMWH therapy, that is, above the baseline increased risk of bleeding among patients with renal insufficiency.

The product labeling for the drugs in our review all recommend decreased dosing for VTE prophylaxis in patients with renal insufficiency. However, these recommendations are not backed by cited peer-reviewed literature. Therefore, we see a great need for future studies to assess the relative safety and efficacy of VTE prophylaxis regimens in patients with compromised renal function.

## Limitations

Our systematic review identified important weaknesses in the literature. We did not identify high quality RCTs on any of these KQs. The RCTs identified for some of these KQs were small and had methodological limitations. The majorities of observational studies included in this review were at high risk of bias and did not report on several quality items of interest. The greatest risk to their validity was confounding by indication in that the sicker patients received more intense prophylaxis than the less sick patients, with no or inadequate adjustment for differences between treatment groups. The studies were heterogeneous in definition of VTE and bleeding outcomes precluding any meaningful pooling in a meta-analysis. We also did not find data on several pharmacologic comparisons of interest or details about appropriate dosing strategies in these special populations.

Our systematic review has several limitations. Although our search strategy was comprehensive, we may have missed studies. Although we included study designs other than randomized controlled trials in our review, the identification and indexing of observational studies is far more challenging than that of randomized controlled trials. So it is possible we may have missed a few observational studies. The potential impact of this on the strength of our inference is unknown. We were unable to assess the possibility of publication bias or selective outcomes reporting and its impact on our findings. It is difficult to determine the impact of unpublished data on the findings of the systematic review. Although we evaluated a range of important outcomes, we did not evaluate some potential long term complications such as phlegmasia and functional impairment which were beyond the scope of this review.

## Future Research

Our report highlights the need for additional research on the comparative effectiveness and safety of pharmacologic and mechanical strategies to prevent VTE among these special populations. For many of the questions, multicenter clinical trials may be prohibitively expensive or impossible. We describe here options for observational research as well as trials.

There remains a significant research gap regarding the efficacy and safety for IVC filters for PE prophylaxis in trauma patients. The American Venous Forum and the Society of Interventional Radiology Multidisciplinary Consensus Conference have placed a high priority on studies of filters in trauma160 If feasible, a large, multi-center RCT could definitively answer the question on the efficacy and safety of IVC filters in patients with trauma including patients with traumatic brain injury.160 We recognize that this may be prohibitively complex and expensive; therefore, answering this question with well-designed observational research may be optimal. These observational studies could be prospective cohort studies with the exposed group defined as individuals with trauma receiving filters and with a carefully matched comparison group of individuals - having comparable injuries and comorbid conditions - who do not receive filters. Additionally, observational research could be facilitated with use of registry data, such as from the National Trauma Data Bank.33 Although presently there is insufficient detail about filter placement in this registry, this could be rectified. This would then allow cohort studies to be nested within this registry. The information that would need to be captured would be filter related information including timing, indication, type of filter, as well as complications from placement. Such studies should also adequately determine the utility of surveillance for VTE prophylaxis.

Retrospective cohort studies may also be valuable for this question but there needs to be much better control for confounding by indication than was done in the studies included in this review. The major flaw of the included retrospective studies was that the authors compared the outcomes for patients receiving filters with patients not receiving filters with little attention to differences among these patients. Commonly, the patients receiving filters were at greater risk for thrombotic complications (or other adverse outcomes) than patients without filters. With careful risk adjustment through regression or the use of other methods such as propensity score matching or instrumental variable analyses, valid inferences can be drawn from retrospective studies. We identified very few studies that used propensity score methods, and even the use of multivariate regression techniques was limited.

Future studies should also attempt to determine the reasons for low filter retrieval rates. Filter related complications may be obviated by timely removal of filters; if this is not happening, there needs to be better understanding of why not and a testing of interventions to improve retrieval rates.

We found that few studies reported on post-thrombotic syndrome as an outcome for filter studies. Future studies should report on these outcomes. These studies should help inform the degree to which the recurrent DVT episodes, potentially associated with filters, result in long-term sequelae from post-thrombotic syndrome.

Additional studies among patients with traumatic brain injury are still needed to determine whether pharmacologic DVT prophylaxis should be used for these patients, and the optimal timing of administration. This very well may require trials. The level of detail about timing of dosing in observational data may be limited. Studies should also determine how to better risk stratify patients to inform decisions about pharmacologic prophylaxis. This could be addressed with observational studies describing outcomes of patients in different strata of risk.

Unquestionably, severe burns may induce pathophysiological changes that alter the pharmacokinetic parameters of drugs, such as volume of distribution and clearance. 173 For this systematic review, we searched for studies that measured the effect of pharmacologic strategies on anti-Xa concentration, which is a reasonable surrogate for bleeding risk, for the Key Questions addressing patients with renal insufficiency and obesity and underweight. Pharmacokinetic studies are needed in other patient populations to determine whether altered pharmacokinetics of enoxaparin may result in inadequate dosing in burn patients, and whether dose-adjustment of enoxaparin based on serum anti-Xa monitoring is warranted.174 Observational studies using electronic health records should be feasible and can answer this question. Electronic health record data would provide sufficient information about the exposures to the pharmacologic and mechanical interventions, and outcomes; and should allow for controlling for confounding by indication with information about comorbid conditions, burn severity and surface area affected. Given that there are likely important institutional differences in practice patterns regarding prophylaxis of burns, the use of the institution as an instrumental variable is conceivable (assuming that the patient mix is comparable across institutions). Future studies should adequately consider the role of specific risk factors for VTE in burn patients such as body surface area, age, body mass index, concomitant injuries, mobility states and the presence of central venous lines.

Future research should include high-quality observational studies to determine the comparative effectiveness and safety of various pharmacological and mechanical strategies among patients with liver disease. Such studies should characterize the relative risks of bleeding and thrombosis across stages of liver disease, which will require clinical information such as from electronic health records.

The question of elevated risk of bleeding with dual therapy with prophylactic anticoagulation and aspirin therapy remains unanswered. Rare events such as bleeding from prophylactic doses of anticoagulation are difficult to answer in trials; this question too will require high-quality observational studies that control for confounding by indication with the use of propensity score methods or possibly instrumental variables.

Trials of IVC filters in patients undergoing bariatric surgery might not be warranted. There is established value of pharmacologic prophylaxis in this patient population, so that RCTs that do not allow pharmacological treatment might be considered to be unethical. Similarly, because the rates of events are so low in patients with pharmacological treatment, exposing individuals to filter placement in an RCT may expose them to complication risk while there is little opportunity to demonstrate improvement in PE rates over the existing low rates. Such trials should include only those patients deemed to be at highest risk for VTE complications, such as those with prior VTE. RCTs might address whether standard doses of prophylaxis that have been proven safe and effective in other types of surgery (such as 5,000 units of subcutaneous unfractionated heparin three times daily, enoxaparin 30 mg twice daily, or enoxaparin 40 mg once daily) are adequate for patients undergoing bariatric surgery. We suggest that weight-based dosing compared with fixed-dosing, rather than BMI-based dosing compared with fixed-dosing, is the more relevant scientific question.

RCTs should evaluate the comparative effectiveness and safety of LMWHs in obese patients. Such trials need to ensure that those at both extremes of weight the underweight (BMI < 18 kg/m^2^) and severely obese (BMI > 40 kg/m^2^) are adequately represented in these trials. RCTs of VTE prevention will ideally report data on subgroups of obese and overweight patients, as well as subgroups of patients defined by renal impairment status. Future trials should seek to enroll a subpopulation of patients with renal insufficiency to add to this body of evidence. Observational analyses may be useful for this question as well. We propose that large trials that have been completed should report subgroup results, including subgroups that were not specified at the start of the trial, so that this information is available to researchers doing meta-analysis.175 Whereas the results in these subgroups might be considered exploratory in the context of the parent trial, when pooled across studies, the added power may allow for stronger, yet cautious, conclusions.

Even with evidence for the above, it still may not be clear as to what is the best practice as this may depend on patients' preferences for the possible outcomes. Post-thrombotic syndrome is an unfortunate outcome that is not often addressed in studies of prophylaxis, but which may importantly affect a patient's quality of life. An individual's tolerance of risk without an intervention may exceed his tolerance of a different risk with an intervention, and this has importance for decision making. These questions are best answered with qualitative methods or possibly with quantitative methods designed for learning patients' preferences. These can then be used in decision-analytic models that may be informative to clinicians and patients.

## Conclusion

Our systematic review summarizes the current state of the evidence on the role of pharmacologic and mechanical prophylaxis for the prevention of VTE among these special populations. Our review demonstrates a paucity of evidence from high quality studies to inform these Key Questions for these special populations. Our systematic review identified important weaknesses in the literature. Future research using high quality observational studies that control for confounding by indication, such as provider and practice patterns, and confounding by disease severity may be needed as randomized controlled trials typically exclude or do not report on these special populations.