# Clinical Trials

Table 1 Clinical Trials

Clinical Trial Name and Identifier | Relevant To KQ | Comments
Delayed Versus Early Enoxaparin Prophylaxis After Traumatic Brain Injury (TBI) (DEEP) NCT01014403 | KQ2 | Included in our review
Fondaparinux 1.5 mg for the Prevention of Venous Thromboembolism (VTE) in Medical Patients With Renal Insufficiency NCT00927602 | KQ8 | Study was terminated due to slow recruitment; there are no published results; these study results would be relevant to KQ8
A Comparison of Certoparin and Unfractionated Heparin in the Prevention of Thromboembolic Events in Acutely Ill Medical Patients NCT00451412 | KQ4,5,7,8 | Included in our review
Efficacy of the Association Mechanical Prophylaxis + Anticoagulant Prophylaxis on Venous Thromboembolism Incidence in Intensive Care Unit (ICU) (CIREA2) NCT00740987 | KQ4,5,7,8 | Recruiting patients, results not available yet; unlikely to inform any of the key questions when available
Safety of Fondaparinux as Routine VTE Prophylaxis in Medical ICU Patients NCT00493896 | KQ4,5,7,8 | Study was terminated for slow enrollment; no published results
Fondaparinux in Critically Ill Patients With Renal Failure NCT01467583 | KQ8 | Recruiting patients, results not available yet; results on the subgroup of patients with acute renal failure but not on dialysis will inform KQ8
Thromboprophylaxis and Bariatric Surgery NCT00444652 | KQ6 | Recruiting patients, results not available yet but will inform KQ6; will not obviate the need for future research regarding pharmacoprophylaxis; this is an industry sponsored study of intermediate outcomes
Prospective, Multi-center, Single-arm Study to Assess the Safety of Retrieval of the Recovery G2 Filter (EVEREST) NCT00556426 | KQ1,KQ6 | Study completed; no published results; results will be informative to our key questions if results are reported by patient subgroups; will not obviate the need for future research for these questions
IVC Filter Registry NCT01158482 | KQ1,KQ6 | Recruiting patients; will allow for observational studies
National Inferior Vena Cava (IVC) Filter Registry NCT01367184 | KQ1,KQ6 | Recruiting patients; will allow for observational studies
Crux Biomedical Vena Cava Filter Study - United States (RETRIEVE 2) NCT01120509 | KQ1,KQ6 | Study completed; no published results; observational study relevant to KQ1 and KQ6 if subgroups are reported
Crux Biomedical IVC Filter - Evaluation of the Crux Inferior Vena Cava Filter System (Retrieve) NCT00605332 | KQ1,KQ6 | Study completed; no published results; observational study relevant to KQ1 and KQ6 if subgroups are reported; does not obviate need for additional research