# Sensitivity Analysis for KQ 1 and KQ 6

Table 1 Sensitivity analysis for KQ 1

Outcome | Meta-analysis | Continuity correction | Effect estimate and 95% CI | Effect estimate and 95% CI (Stata) | Statistical heterogeneity, % | Statistical heterogeneity (Stata)
PE1-6 | RR Random effects | 0.1 | 0.13 (95% CI = 0.02 to 0.92) * | 0.13 (95% CI = 0.02 to 0.92) * | 0 % | 0%
PE1-6 | RR Random effects | 0.5 | 0.23 (95% CI = 0.08 to 0.68) * | 0.23 (95% CI = 0.08 to 0.68) * | 0% | 0%
PE1-6 | RR Random effects | Treatment arm | 0.20 (95% CI = 0.06 to 0.70)^*^ | 0.20 (0.06 to 0.70) * | 0% | 0%
PE1-6 | Peto OR | No CC | 0.26 (95% CI = 0.14 to 0.49)^*^ | 0.26 (95% CI = 0.14 to 0.49^*^ | 0% | 0%
Fatal PE3 5 6 | RR Random effects | 0.1 | 0.01 (95% CI = 0to 425.491) | 0.005 (95% CI = 0 to 425.5) | 0 % | 0%
Fatal PE3 5 6 | RR Random effects | 0.5 | 0.22 (95% CI = 0.04 to 1.16) | 0.22 (95% CI = 0.04 to 1.16) | 0% | 0%
Fatal PE3 5 6 | RR Random effects | Treatment arm | 0.09 (95% CI = 0.01 to .76) * | 0.09 (0.01 to 0.81) * | 0% | 0%
Fatal PE3 5 6 | Peto OR | No CC | 0.22 (95% CI = 0.08to 0.58) * | 0.22 (95% CI = 0.08 to 0.58) * | 0% | 0%
Mortality3-5 | RR Random effects | 0.1 | 0.70 (95% CI = 0.44 to 1.11) | 0.7 (95% CI = 0.44 to 1.11) | 0 % | 0%
Mortality3-5 | RR Random effects | 0.5 | 0.70 (95% CI = 0.41 to 1.19) | 0.71 (95% CI = 0.41 to 1.20) | 4.6% | 4.7%
Mortality3-5 | RR Random effects | Treatment arm | 0.70 (95% CI = 0.40 to 1.22) | 0.70 (0.40 to 1.23) | 6.6% | 6.7%
Mortality3-5 | Peto OR | No CC | 0.66 (95% CI = 0.39 to 1.09) | 0.66 (95% CI = 0.39 to 1.09) | 20.3% | 20.3%
DVT1 4 5 | RR Random effects | 0.1 | 1.69 (95% CI = 0.41 to 6.99) | 1.69 (95% CI = 0.41 to 6.99) | 57.2% | 57.2%
DVT1 4 5 | RR Random effects | 0.5 | 1.74 (95% CI = 0.49 to 6.077) | 1.74 (95% CI = 0.5 to 6.07) | 56.5 | 56.4%
DVT1 4 5 | RR Random effects | Treatment arm | 1.76 (95% CI = 0.50 to 6.19) | 1.76 (0.5 to 6.19) | 56.8% | 56.7%
DVT1 4 5 | Peto OR | No CC | 1.67 (95% CI = 0.81 to 3.47) | 1.67 (95% CI = 0.81 to 3.47) | 60.6% | 60.6%

* Statistically significant

Table 2 Sensitivity analysis for KQ 6

Outcome | Meta-analysis | Continuity correction | Effect estimate and 95% CI | Effect estimate and 95% CI (Stata) | Statistical heterogeneity | Statistical heterogeneity (Stata)
PE1-5 | RR Random effects | 0.1 | 1.30 (95% CI = 0.57 to 3.01) | 1.30 (95% CI = 0.57 to 3.01) | 11.2% | 11.2%
PE1-5 | RR Random effects | 0.5 | 1.16 (95% CI = 0.51 to 2.66) | 1.17 (95% CI = 0.51 to 2.67) | 16.0% | 16.0%
PE1-5 | RR Random effects | Treatment arm | 1.21 (95% CI = 0.57 to 2.56) | 1.21 (95% CI = 0.57 to 2.56) | 6.9% | 6.9%
PE1-5 | Peto OR | No CC | 0.99 (95% CI = 0.49 to 2.00) | 0.99 (95% CI = 0.49 to 1.96) | 36.2% | 36.2%
Mortality1-4 | RR Random effects | 0.1 | 5.95 (95% CI = 1.99 to 17.81) | 5.95 (95% CI = 1.99 to 17.81) * | 0% | 0%
Mortality1-4 | RR Random effects | 0.5 | 4.45 (95% CI = 1.55 to 12.72) | 4.45 (95% CI = 1.55 to 12.72) * | 4.1% | 4.1%
Mortality1-4 | RR Random effects | Treatment arm | 4.30 (95% CI = 1.60 to 11.54) | 4.30 (95% CI = 1.60 to 11.54) * | 0% | 0%
Mortality1-4 | Peto OR | No CC | 3.87 (95% CI = 1.32 to 11.35) * | 3.87 (95% CI = 1.32 to 11.35) * | 70.5% | 70.5%
DVT1 3-5 | RR Random effects | 0.1 | 2.94 (95% CI = 1.35 to 6.38) | 2.93 (95% CI = 1.35 to 6.38) * | 40.3% | 42.2%
DVT1 3-5 | RR Random effects | 0.5 | 2.94 (95% CI = 1.35 to 6.38) | 3.13 (95% CI = 1.39 to 7.06) * | 40.3% | 40.3%
DVT1 3-5 | RR Random effects | Treatment arm | 2.94 (95% CI = 1.35 to 6.38) | 2.93 (95% CI = 1.35 to 6.38) * | 40.3% | 40.3%
DVT1 3-5 | Peto OR | No CC | 2.93 (95% CI = 1.49 to 5.78) * | 2.93 (95% CI = 1.49 to 5.78) * | 78% | 78%

* Statistically significant

## Table 1 References

1 Gorman PH, Qadri SF, Rao-Patel A. Prophylactic inferior vena cava (IVC) filter placement may increase the relative risk of deep venous thrombosis after acute spinal cord injury. J Trauma. 2009;66(3):707-12. [pmid: 19276742].
2 Gosin JS, Graham AM, Ciocca RG, Hammond JS. Efficacy of prophylactic vena cava filters in high-risk trauma patients. Ann Vasc Surg. 1997;11(1):100-5. [pmid: 9061147].
3 Khansarinia S, Dennis JW, Veldenz HC, Butcher JL, Hartland L. Prophylactic Greenfield filter placement in selected high-risk trauma patients. J Vasc Surg. 1995;22(3):231-5. discussion 235-6. [pmid: 7674465].
4 Rajasekhar A, Lottenberg L, Lottenberg R, et al. A pilot study on the randomization of inferior vena cava filter placement for venous thromboembolism prophylaxis in high-risk trauma patients. J Trauma. 2011;71(2):323-9. [pmid: 21825934].
5 Rodriguez JL, Lopez JM, Proctor MC, et al. Early placement of prophylactic vena caval filters in injured patients at high risk for pulmonary embolism. J Trauma. 1996;40(5):797-802. discussion 802-4. [pmid: 8614083].
6 Wilson JT, Rogers FB, Wald SL, Shackford SR, Ricci MA. Prophylactic vena cava filter insertion in patients with traumatic spinal cord injury: preliminary results. Neurosurgery. 1994;35(2):234-9. discussion 239. [pmid: 7969830].

## Table 2 References

1 Birkmeyer NJ, Share D, Baser O, et al. Preoperative placement of inferior vena cava filters and outcomes after gastric bypass surgery. Ann Surg. 2010;252(2):313-8. Notes: CORPORATE NAME: Michigan Bariatric Surgery Collaborative. [pmid: 20622663].
2 Gargiulo NJ 3rd, Veith FJ, Lipsitz EC, Suggs WD, Ohki T, Goodman E. Experience with inferior vena cava filter placement in patients undergoing open gastric bypass procedures. J Vasc Surg. 2006;44(6):1301-5. [pmid: 17055691].
3 Li W, Gorecki P, Semaan E, Briggs W, Tortolani AJ, D'Ayala M. Concurrent prophylactic placement of inferior vena cava filter in gastric bypass and adjustable banding operations in the Bariatric Outcomes Longitudinal Database. J Vasc Surg. 2012;55(6):1690-5. [pmid: 22360915].
4 Obeid FN, Bowling WM, Fike JS, Durant JA. Efficacy of prophylactic inferior vena cava filter placement in bariatric surgery. Surg Obes Relat Dis. 2007;3(6):606-8. discussion 609-10. [pmid: 17936083].
5 Overby DW, Kohn GP, Cahan MA, et al. Risk-group targeted inferior vena cava filter placement in gastric bypass patients. Obes Surg. 2009;19(4):451-5. [pmid: 19127387].