# Sensitivity Analysis for IVC Filters in Trauma on PE, Fatal PE, and Mortality in Controlled Studies

Table 1 Sensitivity analysis for IVC filters in trauma on PE, fatal PE and mortality in controlled studies

| RR ( 95% CI) | Statistical inconsistency I^2,^ %
PE
All Studies | 0.55 ( 0.10-2.96) | 61
Wilson excluded | 0.62 ( 0.10-3.68 | 66.3
Rogers 1995 excluded | 0.44 (0.06-3.09) | 62
Khansarina excluded | 0.76 ( 0.13-4.34) | 60.7
Rodriguez excluded | 0.70 ( 0.10-5.05) | 63.6
Rogers 1997 excluded | 0.33( 0.09-1.33) | 30
Gosin excluded | 0.72( 0.12-4.25) | 62.7
Gorman excluded | 0.43 (0.07-2.75) | 64.6
Rajashekhar excluded | 0.58(0.08-4.05) | 67.2
Rogers 1995; Rogers 1997 excluded | 0.20 (0.06-0.70) | 0
FATAL PE
All Studies | 0.35 ( 0.01-8.16) | 70
Wilson excluded | 0.37 (0.01to 17.31) | 80
Rogers 1995 excluded | 0.09(0.01 to 0.81) | 0
Khansarina excluded | 0.59 (0.01 to 30.79) | 73.4
Rodriguez excluded | 0.57 ( 0.01 to 32.80) | 74.9
MORTALITY
All Studies | 1.33 (0.53 to 3.32) | 69.8
Rogers 1995 excluded | 0.95(0.41 to 2.22) | 55
Khansarina excluded | 1.66 ( 0.46-5.97) | 68.5
Rodriguez excluded | 1.82 (90.68 to 4.85) | 69.7
Rogers 1997 excluded | 1.14 ( 0.36 to 3.62) | 70.8
Rajashekhar 2011 excluded | 1.26 (0.47 to 3.37) | 76.8
DVT
All studies | 1.76 (0.49-6.18) | 56.8
Rodriguez excluded | 3.78 ( 1.21 to 11.8) | Not estimable
Gorman excluded | 0.87 ( 0.38 to 2.02) | Not estimable
Rajasekhar excluded | 1.67 (0.35 to 8.04) | Not estimable