# Scientific Information Packet Tables

Table 1 SIP Submission - Statement Indicating No Relevant Studies Have been Conducted

Company | Product | Description of Submission | Number of Published Studies | Number of Unpublished Studies | Number of Clinical Trials
APP Pharmaceuticals | Heparin Sodium Injection | Letter stating that no relevant studies had been conducted with this drug | 0 | 0 | 0
Bayer | Refludan (Lepirudin) | Letter stating that no relevant studies had been conducted with this drug | 0 | 0 | 0
The Medicines Company | Bivalirudin | Letter stating that no relevant studies had been conducted with this drug | 0 | 0 | 0

Table 2 SIP Submission - Potentially Relevant Studies

Company | Product | Description of Submission | Number of Published Studies | Number of Unpublished Studies | Number of Clinical Trials | Citations not previously included in database
Boehringer Ingelheim | Pradaxa (Dabigatran) | Prescribing information and relevant study citations | 7 | 0 | 9 | Of the 36 citations submitted, six were found to be missing from the previously created database. These six studies were then reviewed for eligibility.
Sanofi-Aventis | Lovenox (Enoxaparin) | Prescribing information and relevant study citations | 14 | 0 | 6 | Of the 36 citations submitted, six were found to be missing from the previously created database. These six studies were then reviewed for eligibility.
Covidien | Kendall SCD™ Sequential Compression and A-V Impulse | Journal articles | 12 | 0 | 0 | Of the 36 citations submitted, six were found to be missing from the previously created database. These six studies were then reviewed for eligibility.
GlaxoSmithKline | Arixtra (Fondaparinux) | Prescribing information, relevant citations, and study data | 3 | 1 | 6 | Of the 36 citations submitted, six were found to be missing from the previously created database. These six studies were then reviewed for eligibility.

Table 3 SIP Submission – Chemoprophylaxis Protocol

Organization | Description of Submission | Additional Study Information
American Association of Neurological Surgeons | Chemoprophylaxis Protocol Following Traumatic Brain Injury | Safety of a DVT Chemoprophylaxis Protocol Following Traumatic Brain Injury: A Single Center Quality Improvement Initiative. (Publication Pending) Christopher M Nickele MD^1^, Timothy K Kamps^2^, Joshua E Medow MD^1^ ^1^ Department of Neurologic Surgery, University of Wisconsin, Madison, Wisconsin, United States of America ^2^ Department of Quality Resources, University of Wisconsin, Madison, Wisconsin, United States of America